# Appendix E: Listing of Included and Excluded Articles

## Included Articles

The South-East London Screening Study. A controlled trial of multiphasic screening in middle-age: results of the South-East London Screening Study. 1977. Int J Epidemiol 2001; 30(5):935–40.
Belcher DW. Implementing preventive services. Success and failure in an outpatient trial. Arch Intern Med. 1990;150(12):2533-41. [pmid: 2244769].
Bernacki EJ, Tsai SP, Malone RD. Participation in a periodic physical examination program and group health care utilization and costs. J Occup Med. 1988;30(12):949-52. [pmid: 3230446].
Burton LC, German PS, Shapiro S. A preventive services demonstration. Health status, health behaviors, and cost outcomes 2 years after intervention. The Johns Hopkins Medicare Preventive Services Demonstration Team. Med Care. 1997;35(11):1149-57. [pmid: 9366893].
Burton LC, Steinwachs DM, German PS, et al. Preventive services for the elderly: would coverage affect utilization and costs under Medicare?. Am J Public Health. 1995;85(3):387-91. [pmid: 7892924]. [pmcid: 1614868].
Burton LC, Paglia MJ, German PS, et al. The effect among older persons of a general preventive visit on three health behaviors: Smoking, excessive alcohol drinking, and sedentary lifestyle. Prev Med.
Burton WN, Chen CY, Conti DJ, Schultz AB, Edington DW. The value of the periodic executive health examination: experience at Bank One and summary of the literature. J Occup Environ Med. 2002;44(8):737-44. [pmid: 12185794].
Chiou CJ, Chang HY. Do the elderly benefit from annual physical examination? An example from Kaohsiung City, Taiwan. Prev Med. 2002;35(3):264-70. [pmid: 12202069].
Christensen B. Payment and attendance at general practice preventive health examinations. Fam Med. 1995;27(8):531-4. [pmid: 8522084].
Collen MF, Dales LG, Friedman GD, Flagle CD, Feldman R, Siegelaub AB. Multiphasic checkup evaluation study. 4. Preliminary cost benefit analysis for middle-aged men. Prev Med. 1973;2(2):236-46. [pmid: 4723639].
Cutler JL, Ramcharan S, Feldman R, et al. Multiphasic checkup evaluation study. 1. Methods and population. Prev Med. 1973;2(2):197-206. [pmid: 4723635].
Dales LG, Friedman GD, Ramcharan S, et al. Multiphasic checkup evaluation study. 3. Outpatient clinic utilization, hospitalization, and mortality experience after seven years. Prev Med. 1973;2(2):221-35. [pmid: 4723638].
Dales LG, Friedman GD, Collen MF. Evaluating periodic multiphasic health checkups: a controlled trial. J Chronic Dis 1979.
Eaton CB, Goodwin MA, Stange KC. Direct observation of nutrition counseling in community family practice. Am J Prev Med. 2002;23(3):174-9. [pmid: 12350449].
Elder JP, Williams SJ, Drew JA, Wright BL, Boulan TE. Longitudinal effects of preventive services on health behaviors among an elderly cohort. Am J Prev Med. 1995;11(6):354-9. [pmid: 8775655].
Faulkner LA, Schauffler HH. The effect of health insurance coverage on the appropriate use of recommended clinical preventive services. Am J Prev Med. 1997;13(6):453-8. [pmid: 9415792].
Finkelstein MM. Preventive screening. What factors influence testing?. Can Fam Physician. 2002;48:1494-501. [pmid: 12371308]. [pmcid: 2214098].
Fletcher SW, Sourkes M, Rabzel M, Fletcher RH. Multiphasic screening. Case-finding tool in a Teaching Hospital Medical Clinic. JAMA. 1977;237(9):887-91. [pmid: 576328].
Flocke SA, Stange KC. Direct observation and patient recall of health behavior advice. Prev Med. 2004;38(3):343-9. [pmid: 14766118].
Freedman A, Pimlott N, Naglie G. Preventive care for the elderly. Do family physicians comply with recommendations of the Canadian Task Force on Preventive Health Care?. Can Fam Physician. 2000;46:350-7. [pmid: 10690491]. [pmcid: 1987685].
Friedman GD, Collen MF, Fireman BH. Multiphasic Health Checkup Evaluation: a 16-year follow-up. J Chronic Dis 1986.
Geiger WJ, Neuberger MJ, Bell GC. Implementing the US preventive services guidelines in a family practice residency. Fam Med. 1993;25(7):447-51. [pmid: 8375602].
German PS, Burton LC, Shapiro S, et al. Extended coverage for preventive services for the elderly: response and results in a demonstration population. Am J Public Health. 1995;85(3):379-86. [pmid: 7892923]. [pmcid: 1614862].
Grimaldi JV. The Worth of Occupational Health Programs: A New Evaluation of Periodic Physical Examinations. J Gnathol. 1965;56:365-74.
Hahn DL. The delivery of clinical preventive services: acute care intervention. J Fam Pract. 1999;48(10):785-9. [pmid: 12224676].
Hama Y, Masumori K, Tagami H, Fujiwara K, Kusano S. Preassignment examination for personnel on Iwo Jima. Mil Med. 2001;166(8):721-4. [pmid: 11515325].
Kottke TE, Solberg LI, Brekke ML, Cabrera A, Marquez MA. Delivery rates for preventive services in 44 midwestern clinics. Mayo Clin Proc. 1997;72(6):515-23. [pmid: 9179135].
Lin SX, Gebbie KM, Fullilove RE, Arons RR. Do nurse practitioners make a difference in provision of health counseling in hospital outpatient departments?. J Am Acad Nurse Pract. 2004;16(10):462-6. [pmid: 15543924].
Mayer JA, Jermanovich A, Wright BL, Elder JP, Drew JA, Williams SJ. Changes in health behaviors of older adults: the San Diego Medicare Preventive Health Project. Prev Med. 1994;23(2):127-33. [pmid: 8047517].
Morrissey JP, Harris RP, Kincade-Norburn J, et al. Medicare reimbursement for preventive care. Changes in performance of services, quality of life, and health care costs. Med Care. 1995;33(4):315-31. [pmid: 7731275].
Nakanishi N, Tatara K, Fujiwara H. Do preventive health services reduce eventual demand for medical care? 1996.
Norinder A, Persson U, Nilsson P, Nilsson J A, Hedblad B, Berglund G. Costs for screening, intervention and hospital treatment generated by the Malmo Preventive Project: a large-scale community screening programme. 2002.
Norman P, Conner M. Health checks in general practice: the patient's response. Fam Pract. 1992;9(4):481-7. [pmid: 1490543].
Nutting PA, Baier M, Werner JJ, Cutter G, Conry C, Stewart L. Competing demands in the office visit: what influences mammography recommendations?. J Am Board Fam Pract. 2001;14(5):352-61. [pmid: 11572540].
OXCHECK. Effectiveness of health checks conducted by nurses in primary care: final results of the OXCHECK study. Imperial Cancer Research Fund OXCHECK Study Group. BMJ 1995b; 310(6987):1099–104.
OXCHECK. Effectiveness of health checks conducted by nurses in primary care: results of the OXCHECK study after one year. Imperial Cancer Research Fund OXCHECK Study Group. BMJ (Clinical Research Ed) 1995a.
Parchman M, Byrd T. Access to and use of ambulatory health care by a vulnerable Mexican American population on the U.S.-Mexico border. J Health Care Poor Underserved. 2001;12(4):404-14. [pmid: 11688192].
Patrick DL, Grembowski D, Durham M, et al. Cost and outcomes of Medicare reimbursement for HMO preventive services. Health Care Financ Rev. 1999;20(4):25-43. [pmid: 11482123].
Patrick DL, Grembowski D, Durham M, et al. Cost and outcomes of Medicare reimbursement for HMO preventive services. Health Care Financ Rev. 1999.
Ramcharan S, Cutler JL, Feldman R, et al. Multiphasic checkup evaluation study. 2. Disabilty and chronic disease after seven years of multiphasic health checkups. Prev Med. 1973;2(2):207-20. [pmid: 4723637].
Roberts NJ, Ipsen J, Elsom KO, Clark TW, Yanagawa H. Mortality among males in periodic-health-examination programs. N Engl J Med. 1969;281(1):20-4. [pmid: 5785733].
Schneider GW, DeHaven M, Snell LM. Fostering a culture of prevention in a residency program through a continuous quality improvement project. Am J Med Qual. 2003;18(2):82-9. [pmid: 12710557].
Slesinger DP, Tessler RC, Mechanic D. The effects of social characteristics on the utilization of preventive medical services in contrasting health care programs. Med Care. 1976;14(5):392-404. [pmid: 1271880].
Somkin CP, McPhee SJ, Nguyen T, et al. The effect of access and satisfaction on regular mammogram and Papanicolaou test screening in a multiethnic population. Med Care. 2004;42(9):914-26. [pmid: 15319618]. [pmcid: 1618783].
Sox CH, Dietrich AJ, Tosteson TD, Winchell CW, Labaree CE. Periodic health examinations and the provision of cancer prevention services. Arch Fam Med. 1997;6(3):223-30. [pmid: 9161346].
Stange KC, Flocke SA, Goodwin MA, Kelly RB, Zyzanski SJ. Direct observation of rates of preventive service delivery in community family practice. Prev Med. 2000;31(2 Pt 1):167-76. [pmid: 10938218].
Stone DH, D'Souza MF. Multiphasic screening in middle age: results and implications of a controlled trial in British general practice. Isr J Med Sci. 1981;17(23):215-21. [pmid: 7228648].
Stone DH, Shannon DJ. Screening for impaired visual acuity in middle age in general practice. Br Med J. 1978;2(6141):859-61. [pmid: 709095]. [pmcid: 1607952].
Stone DH CA. The effect of multiphasic screening on aspects of psychiatric status in middle age: results of a controlled trial in general practice. Int J Epidemiol.
Tao G, Zhang P, Li Q. Services provided to nonpregnant women during general medical and gynecologic examinations in the United States. Am J Prev Med. 2001;21(4):291-7. [pmid: 11701300].
The South-East London Screening Study Group. A controlled trial of multiphasic screening in middle-age: results of the South-East London Screening Study. The South-East London Screening Study Group. Int J Epidemiol 1977; 6(4):357–63.
Theobald H. Bygren LO, Carstensen J, Hauffman M, Engfeldt P. Effects of an assessment of needs for medical and social services on long-term mortality: a randomized controlled study. Int J Epidemiol 1998.
Trevelyan H. Study of evaluate the effects of multiphasic screening within general practice in Britain: design and method. Prev Med. 1973;2(2):278-94. [pmid: 4723641].
Williams RB, Boles M, Johnson RE. A patient-initiated system for preventive health care. A randomized trial in community-based primary care practices. Arch Fam Med. 1998;7(4):338-45. [pmid: 9682687].

## Excluded Articles

Affinity Health Plan pays capitated doctors for preventive services. Capitation Manag Rep. 2004. 11(6):70–2 Exposure not the PHE
Health status of American Indians compared with other racial/ethnic minority populations--selected states, 2001–2002. MMWR Morb Mortal Wkly Rep. 2003. 52(47):1148–52 Exposure not the PHE
The evolution of the annual checkup. Mayo Clin Womens Healthsource. 2002. 6(12):1–2 No original data
Health insurance coverage and receipt of preventive health services--United States, 1993. MMWR Morb Mortal Wkly Rep. 95. 44(11):219–25 Exposure not the PHE
From the Centers for Disease Control. Cardiovascular disease, motor-vehicle-related injury, and use of clinical preventive services--Behavioral Risk Factor Surveillance System, 1989. JAMA. 91. 266(8):1068 Article focuses on specific preventive measures only
Cardiovascular disease, motor-vehicle-related injury, and use of clinical preventive services--behavioral risk factor surveillance system, 1989. MMWR Morb Mortal Wkly Rep. 91. 40(28):477–482 Article focuses on specific preventive measures only
Questions and answers about EPSDT--Early and Periodic Screening, Diagnosis and Treatment. J Indiana State Med Assoc. 83. 76(9):651–4 Includes only subjects less than 18 years of age
Automated multiphasic health testing and services (AMHTS). Med Inform (Lond). 82. 7(3):163–266 No original data
Periodic health examination: a guide for designing individualized preventive health care in the asymptomatic patients. Medical Practice Committee, American College of Physicians. Ann Intern Med. 81. 95(6):729–32 No original data
Recommendations for periodic health examinations by the ACP Medical Practice Committee. Am Coll Physicians Obs. 81. 1(12):10–1 Exposure not the PHE
Medicaid requirements for state programs of early and periodic screening, diagnosis, and treatment of individuals under 21: final regulation. Fed Regist. 79. 44(98):29419–27 Exposure not the PHE
Admission multiphasic screening. Lancet. 76. 2(7997):1229–30 No original data
Health services in Europe. 1. Administration and preventive services. WHO Chron. 76. 30(10):407–12 No original data
Multiphasic screening does not always mean better health care, changed behavior. Employee Benefit Plan Rev. 76. 31(2):68, 70 No original data
Massachusetts Department of Public Health. Early and periodic screening, diagnosis and treatment (EPSDT). N Engl J Med. 74. 290(19):1087–8 Includes only subjects less than 18 years of age
Multiphasic screening for state employees at State Park Health Centers. J S C Med Assoc. 74. 70(3):101 Does not apply to any of the key questions
Multiphasic screening in Rhode Island. R I Med J. 72. 55(3):84 No original data
Automated multiphasic health testing. A review of AMHT centers. Hospitals. 71. 45(5):75–87 Exposure not the PHE
Multiphasic screening. N Engl J Med. 71. 284(5):275–8 No original data
Costs of automated multiphasic screening. JAMA. 70. 214(11):2047–8 No original data
Multiphasic screening. Md State Med J. 69. 18(5):133–4 No original data
OCCUPATIONAL health on wheels; periodic physical examinations in mobile units. Ind Med Surg. 55. 24(9):383–91 Exposure not the PHE
THE PERIODIC physical examination. Med Times. 55. 83(8):757–64 Does not apply to any of the key questions
PERIODIC health examinations. J Am Med Assoc. 53. 153(16):1449–50 Does not apply to any of the key questions
ANNUAL physical examinations. Med Bull U S Army Eur Command Med Div. 51. 8(10):465–6 No original data
Abelson J 4th, Lomas J. Do health service organizations and community health centres have higher disease prevention and health promotion levels than fee-for-service practices?. CMAJ. 90;142(6):575-81. Exposure not the PHE.
Achat H, Close G, Taylor R. Who has regular mammograms? Effects of knowledge, beliefs, socioeconomic status, and health-related factors. Prev Med. 2005;41(1):312-20. Does not apply to any of the key questions. [pmid: 15917027].
Adams E. K, Florence C. S, Thorpe K. E, Becker E. R, Joski P. J. Preventive care: female cancer screening, 1996–2000. Am J Prev Med. 2003;25(4):301-7. Exposure not the PHE. [pmid: 14580631].
Adler N. E. Community preventive services. Do we know what we need to know to improve health and reduce disparities?. Am J Prev Med. 2003;24(3 Suppl):10-1. No original data. [pmid: 12668193].
Allander, E., Bring, J., Gudmundsson, L., Mattson, S., Olafsson, O., RignÃ©r, K., Sigurgeirsson, B., and Taube, A. What is the long term value of multiphasic health screening and the initial judgement of benefit? Survival to 85 and 90 years, perceived health and functional ability of participants in the Swedish Eskilstuna study 1964 and 1969, 20 and 25 years later.. No eligible comparison group
Allison J. E, Feldman R. Cost benefits of hemoccult screening for colorectal carcinoma. Dig Dis Sci. 85;30(9):860-5. Article focuses on specific preventive measures only.
Altshuler C. H. Multiphasic screening. JAMA. 72;222(13):1653. Exposure not the PHE. [pmid: 4678376].
Anderson R. T, Weisman C. S, Scholle S. H, Henderson J. T, Oldendick R, Camacho F. Evaluation of the quality of care in the clinical care centers of the National Centers of Excellence in Women's Health. Womens Health Issues. 2002;12(6):309-26. Does not apply to any of the key questions. [pmid: 12457572].
Aparasu R. R, Hegge M. Autonomous ambulatory care by nurse practitioners and physician assistants in office-based settings. J Allied Health. 2001;30(3):153-9. Does not apply to any of the key questions. [pmid: 11582978].
Aena, J. M. A comparison of european health services. 2. PREVENTIVE SERVICES. WHO Chron. 65. 19240–5 Does not apply to any of the key questions
Aubin M, Vezina L, Fortin J. P, Bernard P. M. Effectiveness of a program to improve hypertension screening in primary care. CMAJ. 94;150(4):509-15. Exposure not the PHE.
Ayanian J. Z, Weissman J. S, Schneider E. C, Ginsburg J. A, Zaslavsky A. M. Unmet health needs of uninsured adults in the United States. JAMA. 2000;284(16):2061-9. Exposure not the PHE. [pmid: 11042754].
Ayers W. R, Hochberg H. M, Caceres C. A. Automated multiphasic health testing. Public Health Rep. 69;84(7):582-4. Does not apply to any of the key questions.
Balas E A, Weingarten S Garb C T Blumenthal D Boren S A Brown G D Improving preventive care by prompting physicians (Structured abstract). No original data
Balkrishnan R, Hall M. A, Mehrabi D, Chen G. J, Feldman S. R, Fleischer A. B Jr. Capitation payment, length of visit, and preventive services: evidence from a national sample of outpatient physicians. Am J Manag Care. 2002;8(4):332-40. Exposure not the PHE. [pmid: 11950128].
Banta J. E, Franklin R. R. Cost and technology: significance of multiphasic screening to public health. Clin Eng. 77;5(5):1-6. Exposure not the PHE.
Barnes B. A. Papanicolaou cervical smears for screening in asymptomatic women. Prim Care. 81;8(1):131-40. Exposure not the PHE. [pmid: 6911755].
Barnsley, J., Williams, A. P., Kaczorowski, J., Vayda, E., Vingilis, E., Campbell, A., and Atkin, K. Who provides walk-in services? Survey of primary care practice in Ontario. Can Fam Physician. 2002. 48519–26 Exposure not the PHE
Barr J. K, Franks A. L, Lee N. C, Herther P, Schachter M. Factors associated with continued participation in mammography screening. Prev Med. 2001;33(6):661-7. Exposure not the PHE. [pmid: 11716664].
Baskerville NB, Hogg W Lemelin J Process evaluation of a tailored multifaceted approach to changing family physician practice patterns improving preventive care.. Meeting abstract
Bates B, Yellin J. A. The yield of multiphasic screening. JAMA. 72;222(1):74-8. Exposure not the PHE. [pmid: 5068677].
Bates B, Parker R.C Jr, Reifler C. B. Clinical evaluation and multiphasic screening. A comparison of yields. Ann Intern Med. 71;75(6):929-31. Does not apply to any of the key questions.
Battista R. N, Beaulieu M. D, Feightner J. W, Mann K. V, Owen G. The periodic health examination: 3. An evolving concept. Can Med Assoc J. 84;130(10):1288-92. No original data.
Baugh, C. W. Evaluation of the periodic health examination. Can Med Assoc J. 65. 92983–4 No original data
Baum E, Donner Banzhoff N Jakle C Keller S Miko M Sarafowa A Basler H D Health education and motivation to change. A study of high-risk patients detected by health check-up.. Not English language
Beck A, Scott J, Williams P, Robertson B, Jackson D, Gade G, Cowan P. A randomized trial of group outpatient visits for chronically ill older HMO members: the Cooperative Health Care Clinic. J Am Geriatr Soc. 97;45(5):543-9. Exposure not the PHE.
Beck, L. H. Clinical experience. Periodic health examination and screening tests in adults.. No original data
Becker D. M, Gomez E. B, Kaiser D. L, Yoshihasi A, Hodge R. H Jr. Improving preventive care at a medical clinic: how can the patient help?. Am J Prev Med. 89;5(6):353-9. Exposure not the PHE.
Bednarek H. L, Schone B. S. Variation in preventive service use among the insured and uninsured: does length of time without coverage matter?. J Health Care Poor Underserved. 2003;14(3):403-19. Exposure not the PHE. [pmid: 12955919].
Benadum C. E. Occupational health nurses, a periodic screening examination program, and the computer. Occup Health Nurs. 81;29(7):28-9. Does not apply to any of the key questions.
Benjamins M. R, Kirby J. B, Bond Huie S. A. County characteristics and racial and ethnic disparities in the use of preventive services. Prev Med. 2004;39(4):704-12. Exposure not the PHE. [pmid: 15351536].
Berg GD, Thomas E. Silverstein S. Neel C. L. Mireles M. Reducing medical service utilization by encouraging vaccines: Randomized controlled trial. Exposure not the PHE
Berg, A. O. Screening for lipid disorders in adults: recommendations and rationale.. Article focuses on specific preventive measures only
Berki S. E, Ashcraft M. L. On the analysis of ambulatory utilization: an investigation of the roles of need, access and price as predictors of illness and preventive visits. Med Care. 79;17(12):1163-81. Article focuses on specific preventive measures only.
Bernstein J. M, Dolan L. J. Multiphasic screening as part of family doctoring. Practitioner. 69;203(218):789-805. No eligible comparison group. [pmid: 5356393].
Bertakis K. D, Robbins J. A, Callahan E. J, Helms L. J, Azari R. Physician practice style patterns with established patients: determinants and differences between family practice and general internal medicine residents. Fam Med. 99;31(3):187-94. Exposure not the PHE.
Bertrand C. A, Pomper I, Hillman G, Duffy J. C, Michell I, Trout K. W. Electrocardiogram in multiphasic health testing. N Y State J Med. 77;77(13):2063-7. Exposure not the PHE.
Berwick D. M. Screening in health fairs. A critical review of benefits, risks, and costs. JAMA. 85;254(11):1492-8. Article focuses on specific preventive measures only.
Bhuripanyo K, Leowattana W, Ruangratanaamporn, et al. Are routine checkups necessary?: The Shinawatra's employee study. J Med Assoc Thai. 2000;83(Suppl 2):S163-71. No eligible comparison group. [pmid: 11194009].
Biem H J, Turnell R W D apos Arcy C Computer telephony: automated calls for medical care (Provisional record). Does not apply to any of the key questions
Biles and Abrams, M. Commentary. Clinical preventive services in managed care plans: case studies and next steps.. Does not apply to any of the key questions
Bindman A. B, Grumbach K, Osmond D, Vranizan K, Stewart A. L. Primary care and receipt of preventive services. J Gen Intern Med. 96;11(5):269-76. Exposure not the PHE.
Blair K. A. Cancer screening of older women : a primary care issue. Cancer Pract. 98;6(4):217-22. Article focuses on specific preventive measures only.
Bluestein D. Preventive services: counseling for healthy lifestyles. Geriatrics. 2005;60(4):34-7. Exposure not the PHE.
Bluestein D. Preventive services: immunization and chemoprevention. Geriatrics. 2005;60(3):35-9. Exposure not the PHE. [pmid: 15755191].
Bolt R. J, Mallery O. T Jr, Tupper C. J. An appraisal of laboratory procedures in periodic health examinations. AMA Arch Ind Health. 56;13(3):253-8. Exposure not the PHE.
Bolt R. J, Tupper C. J, Mallery O. T Jr. An appraisal of periodic health examinations. AMA Arch Ind Health. 55;12(4):420-6. No eligible comparison group. [pmid: 13257935].
Bombardier C, McClaran J, Sackett D. Periodic health examinations and multiphasic screening. Can Med Assoc J. 73;109(11):1123-7. No original data. [pmid: 4759494].
Borders T. F, Warner R. D, Sutkin G. Satisfaction with health care and cancer screening practices among women in a largely rural region of West Texas. Prev Med. 2003;36(6):652-8. Exposure not the PHE. [pmid: 12744907].
Boustani M, Peterson B Harris R Lux L J Krasnov C Sutton S F Hanson L Lohr K N Screening for dementia. No original data
Boutwell J. H. Multiphasic health testing. Trans Stud Coll Physicians Phila. 70;37(4):291-4. Does not apply to any of the key questions.
Branch L. G, Rabiner D. J. Rediscovering the patient's role in receiving health promotion services. Med Care. 2000;38(1):70-7. Article focuses on specific preventive measures only. [pmid: 10630721].
Branch L. G, Rabiner D. J, Patterson P, Sullivan R. J Jr. Prevention services received by veterans visiting VHA facilities. Prev Med. 98;27(4):604-10. Article focuses on specific preventive measures only.
Breslow, L. Prevention and control of chronic disease. V. Periodic health examination and multiple screening. Am J Public Health. 59. 491148–56 Does not apply to any of the key questions
Breslow L. Multiphasic screening in California. J Chronic Dis. 55;2(4):375-83. Does not apply to any of the key questions. [pmid: 13263374].
Breslow L. Multiphasic screening examination, an extension of the mass screening technique. Am J Public Health. 50;40(3):274-8. No original data.
Brett, K. M. and Burt, C. W. Utilization of ambulatory medical care by women: United States, 1997–98. Vital Health Stat 13. 2001. (149): 1–46 Does not apply to any of the key questions
Brinton L. A, Williams R. R, Hoover R. N, Stegens N. L, Feinleib M, Fraumeni J. F Jr. Breast cancer risk factors among screening program participants. J Natl Cancer Inst. 79;62(1):37-44. Exposure not the PHE.
Bronson D. L, Flynn B. S, Solomon L. J, Vacek P, Secker-Walker R. H. Smoking cessation counseling during periodic health examinations. Arch Intern Med. 89;149(7):1653-6. Article focuses on specific preventive measures only.
Bown, F. R. Multiphasic screening program including a cardiovascular survey in Carter County, Oklahoma. South Med J. 61. 541383–7 Exposure not the PHE
Brown, P. and Golden, W. E. Second national “report card”: Arkansas" clinical performance still needs improvement.. Exposure not the PHE
Bruhn J. G. The complete health checkup: fad, fiction, or fact. South Med J. 79;72(7):865-8. No original data. [pmid: 451698].
Buchwald D, Furman R, Ashton S, Manson S. Preventive care of older urban American Indians and Alaska natives in primary care. J Gen Intern Med. 2001;16(4):257-61. Exposure not the PHE. [pmid: 11318927]. [pmcid: 1495196].
Burdick, M. B. Nurses and prevention: the leap into the 21st century.. Does not apply to any of the key questions
Burns, C. Clinical preventive services -- where do PNPs stand?... president's message.. No original data
Burrows S. Multiphasic screening--panacea or wasted effort?. J Med Soc N J. 72;69(11):919-23. No original data. [pmid: 4508259].
Burton L. C, Weiner J. P, Stevens G. D, Kasper J. Health outcomes and medicaid costs for frail older individuals: a case study of a MCO versus fee-for-service care. J Am Geriatr Soc. 2002;50(2):382-8. Exposure not the PHE. [pmid: 12028225].
Caldroney, R. D. The periodic health examination. Hosp Pract (Off Ed). 87. 22(7):189, 194, 197 passim No original data
Callahan E. J, Bertakis K. D. A comparison of physician-patient interaction at fee-for-service and HMO sites. Fam Pract Res J. 93;13(2):171-8. Exposure not the PHE.
Campione K. M. Periodic health evaluations should be more than multiphasic screening. Occup Health Saf. 77;46(6):32-5. Does not apply to any of the key questions.
Canadian Task Force on the Periodic Health Examination The periodic health examination. Does not apply to any of the key questions
Carcillo J. A, Diegel J. E, Bartman B. A, Guyer F. R, Kramer S. H. Improved maternal and child health care access in a rural community. J Health Care Poor Underserved. 95;6(1):23-40. Includes only subjects less than 18 years of age.
Carel R. S. Findings in pre-employment examinations. Isr J Med Sci. 92;28(89):666-74. No eligible comparison group. [pmid: 1428827].
Carel R. S, Leshem G. Evaluation of the cost-effectiveness of an automated multiphasic health testing system. Prev Med. 80;9(5):689-97. Does not apply to any of the key questions.
Carel R. S, Meyased-Kfir M. Repeated multiphasic screening examinations: evaluating the process. Methods Inf Med. 93;32(3):195-8. Does not apply to any of the key questions.
Carel R. S, Kahan E, Hart Y, Panush N. Utilization of an automated multiphasic health testing system for performing prehospitalization examinations. Med Care. 82;20(8):871-5. Exposure not the PHE.
Carey T, Weis K, Homer C. Prepaid versus traditional Medicaid plans: effects on preventive health care. J Clin Epidemiol. 90;43(11):1213-20. Exposure not the PHE.
Carney P. A, Dietrich A. J, Freeman D. H Jr, Mott L. A. The periodic health examination provided to asymptomatic older women: an assessment using standardized patients. Ann Intern Med. 93;119(2):129-35. Does not apply to any of the key questions.
Carpiano R. M, Flocke S. A, Frank S. H, Stange K. C. Tools, teamwork, and tenacity: an examination of family practice office system influences on preventive service delivery. Prev Med. 2003;36(2):131-40. Exposure not the PHE. [pmid: 12590987].
Carrasquillo O, Lantigua R. A, Shea S. Preventive services among Medicare beneficiaries with supplemental coverage versus HMO enrollees, medicaid recipients, and elders with no additional coverage. Med Care. 2001;39(6):616-26. Exposure not the PHE. [pmid: 11404644].
Cassard S. D, Weisman C. S, Plichta S. B, Johnson T. L. Physician gender and women's preventive services. J Womens Health. 97;6(2):199-207. Does not apply to any of the key questions.
Cassidy J. M. Periodic health examinations. Occup Health Nurs. 72;20(6):16-8. Exposure not the PHE. [pmid: 5064112].
Celentano D. D, Shapiro S, Weisman C. S. Cancer preventive screening behavior among elderly women. Prev Med. 82;11(4):454-63. Exposure not the PHE. [pmid: 7122435].
Chaudhry R, Kottke T. E, Naessens J. M, Johnson T. J, Nyman M. A, Cornelius L. A, Petersen J. D. Busy physicians and preventive services for adults. Mayo Clin Proc. 2000;75(2):156-62. Exposure not the PHE. [pmid: 10683654].
Cheney C, Ramsdell JW Effect of medical records' checklists on implementation of periodic health measures.. Article focuses on specific preventive measures only
Cheng E, Myers L, Wolf S, Shatin D, Cui X. P, Ellison G, Belin T, Vickrey B. Mobility impairments and use of preventive services in women with multiple sclerosis: observational study. BMJ. 2001;323(7319):968-9. Exposure not the PHE. [pmid: 11679386]. [pmcid: 58661].
Chirikos T N, Christman L K Hunter S Roetzheim R G Cost-effectiveness of an intervention to increase cancer screening in primary care settings (Provisional record). Exposure not the PHE
Chosewood, L. C. Improving patient care. Are your patients getting the preventive services they need?. Does not apply to any of the key questions
Cianci, M. H. Public health nursing in Maryland: our roots.. No original data
Clark E. M. A non-automated multiphasic health testing program in a student health service. Am J Public Health. 73;63(7):610-8. Does not apply to any of the key questions.
Clark, T. W., SchorR, S. S., Elsom, K. O., Hubbard, J. P., and Elsom, K. A. The periodic health examination: evaluation of routine tests and procedures. Ann Intern Med. 61. 541209–22 Does not apply to any of the key questions
Cohen SJ, Weinberger M Hui SL Tierney WM McDonald CJ The impact of reading on physicians' nonadherence to recommended standards of medical care.. Exposure not the PHE
Cohen D. I, Littenberg B, Wetzel C, Neuhauser D. Improving physician compliance with preventive medicine guidelines. Med Care. 82;20(10):1040-5. Article focuses on specific preventive measures only.
Cohen R. A, Bloom B, Simpson G, Parsons P. E. Access to health care. Part 3: Older adults. Vital Health Stat 10. 97;(198):1-32. Does not apply to any of the key questions.
Cohn J. M, Koenig F, Baum N. Preventive healthcare in physicians and attorneys. J La State Med Soc. 98;150(6):264-70. Exposure not the PHE. [pmid: 9677785].
Collen M. F. Periodic health examinations using an automated multitest laboratory. JAMA. 66;195(10):830-3. Does not apply to any of the key questions.
Collen M. F. Periodic health evaluations: the multiphasic approach. Internist. 81;22(4):13-5. No original data. [pmid: 10251077].
Collen M. F. Patient data acquisition. Med Instrum. 78;12(4):222-5. Clinical preventive services delivered only durind an opportunistic visit.
Collen M. F. Periodic health examinations. Why? What? When? How?. Prim Care. 76;3(2):197-204. No original data. [pmid: 819951].
Collen M. F. Introduction to multiphasic health testing forum. Prev Med. 73;2(2):175-6. No original data. [pmid: 4723634].
Collen M. F. Automated multiphasic health testing. Implementation of a system. Hospitals. 71;45(5):49-58. No original data. [pmid: 5549278].
Collen M. F, Feldman R, Siegelaub A. B, Crawford D. Dollar cost per positive test for automated multiphasic screening. N Engl J Med. 70;283(9):459-63. Exposure not the PHE.
Collen M. F, Kidd P. H, Feldman R, Cutler J. L. Cost analysis of a multiphasic screening program. N Engl J Med. 69;280(19):1043-5. Does not apply to any of the key questions.
Collen M. F, Rubin L, Neyman J, Dantzig G. B, Baer R. M, Siegelaub A. B. Automated multiphasic screening and diagnosis. 1964. MD Comput. 94;11(3):170-7. Does not apply to any of the key questions.
Collen, M. F., Rubin L., Neyman, J., Dantzig, G. B., Baer, R. M., and Siegelaub, A. B. Automated MULTIPHASIC SCREENING AND DIAGNOSIS. Am J Public Health Nations Health. 64. 54741–50 Does not apply to any of the key questions
Collins, S. D. and Phillips, F. R. Dental, eye, and personal preventive services received by an observed population; sample of white families canvassed at monthly intervals Eastern Health District of Baltimore 1938–43. Public Health Monogr. 53. 161–25 Does not apply to any of the key questions
Comninellis N. B, Harper D. M. Does comprehensive preventive medicine training enhance clinical prevention?. Fam Med. 97;29(2):112-4. Exposure not the PHE.
Constantine H. P. Adult health protection through an automated multiphasic screening center. R I Med J. 68;51(4):258-60. Does not apply to any of the key questions.
Cook W. L Jr. Periodic health examinations. A M A Arch Ind Hyg Occup Med. 53;7(3):241-8. No original data.
Cooper G. S, Goodwin M. A, Stange K. C. The delivery of preventive services for patient symptoms. Am J Prev Med. 2001;21(3):177-81. Exposure not the PHE. [pmid: 11567837].
Copping G. A. The business executive, his nervous tensions, and his periodic health examination. J Occup Med. 67;9(2):59-63. Exposure not the PHE.
Cornelius L. J, Smith P. L, Simpson G. M. What factors hinder women of color from obtaining preventive health care?. Am J Public Health. 2002;92(4):535-9. Exposure not the PHE. [pmid: 11919046]. [pmcid: 1447111].
Cowan J. A. Multiphasic screening tests of state employees explained in detailed report. Mich Med. 69;68(15):852-3. Does not apply to any of the key questions.
Cowan J. A, Heckerling P. S, Parker J. B. Effect of a fact sheet reminder on performance of the periodic health examination: a randomized controlled trial. Am J Prev Med. 92;8(2):104-9. Does not apply to any of the key questions.
Crabtree B. F, Miller W. L, Stange K. C. Understanding practice from the ground up. J Fam Pract. 2001;50(10):881-7. Exposure not the PHE. [pmid: 11674891].
Craig J. L. Automated multiphasic health testing: the TVA experience. Arch Environ Health. 73;27(4):264-6. Does not apply to any of the key questions.
Crumpacker, E. L. and Baker, J. P. Proctosigmoidoscopy in periodic health examinations. JAMA. 61. 1781033–5 Does not apply to any of the key questions
Cummings D. M, Whetstone L, Shende A, Weismiller D. Predictors of screening mammography: implications for office practice. Arch Fam Med. 2000;9(9):870-5. Exposure not the PHE. [pmid: 11031394].
Cummings S. R, Stein M. J, Hansen B, Richard R. J, Gerbert B, Coates T. J. Smoking counseling and preventive medicine. A survey of internists in private practices and a health maintenance organization. Arch Intern Med. 89;149(2):345-9. Exposure not the PHE.
Cunnick W. R, Cromie J. B, Cortell R, Wright B, Beach E, Seltzer F, Miller S. Value of biochemical profiling in a periodic health examination program: analysis of 1,000 cases. Bull N Y Acad Med. 72;18(1):5-22. Does not apply to any of the key questions.
Curry SJ, Ludman EJ Grothaus LC Donovan D Kim E A randomized trial of a brief primary-care-based intervention for reducing at-risk drinking practices.. Exposure not the PHE
D'Epiro, P., Goldbloom, R. Oboler, S. K., and Sox H. C. Jr. Periodic health evaluation: what to include in the evaluation.. No original data
Dandoy, S. Early and periodic screening, diagnosis and treatment program (EPSDT). Ariz Med. 76. 33(1):39–40 Does not apply to any of the key questions
DAVID, W. D. The usefulness of periodic health examinations. Arch Environ Health. 61. 2339–42 Does not apply to any of the key questions
Davidson R. A, Fletcher S. W, Retchin S, Duh S. A nurse-initiated reminder system for the periodic health examination. Implementation and evaluation. Arch Intern Med. 84;144(11):2167-70. Does not apply to any of the key questions.
Davidson R. A, Hale W. E, Moore M. T, May F. E, Marks R. G, Stewart R. B. Incidence of hypertension in an ambulatory elderly population. J Am Geriatr Soc. 89;37(9):861-6. Exposure not the PHE.
Davies H. D, Wang E. E. Periodic health examination, 1996 update: 2. Screening for chlamydial infections. Canadian Task Force on the Periodic Health Examination. CMAJ. 96;154(11):1631-44. Article focuses on specific preventive measures only.
Day E. Is the periodic health examination worthwhile?. Cancer. 81;47(5 Suppl):1210-4. No original data. [pmid: 6786727].
de Nooijer J, Lechner L Candel M de Vries H Short- and long-term effects of tailored information versus general information on determinants and intentions related to early detection of cancer.. Exposure not the PHE
de Raad, J. and Redekop, W. K. Analysis of health factors as predictors for the functioning of military personnel: study of the factors that predict fitness for duty and medical costs of soldiers of the Royal Netherlands Army.. Exposure not the PHE
DeFriese G. H, Hetherington J. S. The “periodic physical examination” as a strategy for prevention in clinical practice. Mobius. 81;1(3):59-65. Does not apply to any of the key questions.
Delbanco T. L. The periodic health examination for the adult. Waste or wisdom?. Prim Care. 76;3(2):205-14. No original data. [pmid: 819952].
Delbanco T. L. The periodic health examination revisited. Ann Intern Med. 75;83(2):271-3. No original data. [pmid: 1147463].
Delbanco T. L, Taylor W. C. The periodic health examination: 1980. Ann Intern Med. 80;92(2 Pt 1):251-2. Does not apply to any of the key questions. [pmid: 7352731].
Delnevo C. D, Steinberg M. B, Abatemarco D. J, Hausman A. J. Correlates of clinical preventive practices among internal medicine residents. Prev Med. 2003;36(6):645-51. Exposure not the PHE. [pmid: 12744906].
DeVoe J. E, Fryer G. E, Phillips R, Green L. Receipt of preventive care among adults: insurance status and usual source of care. Am J Public Health. 2003;93(5):786-91. Exposure not the PHE. [pmid: 12721145]. [pmcid: 1447840].
Diab M. E, Johnston M. V. Relationships between level of disability and receipt of preventive health services. Arch Phys Med Rehabil. 2004;85(5):749-57. No eligible comparison group. [pmid: 15129399].
Diamant A. L, Brook R. H, Fink A, Gelberg L. Use of preventive services in a population of very low-income women. J Health Care Poor Underserved. 2002;13(2):151-63. Exposure not the PHE. [pmid: 12017906].
Dickey L. L, Petitti D. A patient-held minirecord to promote adult preventive care. J Fam Pract. 92;34(4):457-63. Exposure not the PHE. [pmid: 1556540].
Dietrich AJ, Duhamel M Improving geriatric preventive care through a patient-held checklist.. Exposure not the PHE
Dietrich AJ, Woodruff CB Carney PA Changing office routines to enhance preventive care. The preventive GAPS approach.. Does not apply to any of the key questions
Dietrich A. J, Duhamel M. Improving geriatric preventive care through a patient-held checklist. Fam Med. 89;21(3):195-8. Article focuses on specific preventive measures only.
Dietrich A. J, Goldberg H. Preventive content of adult primary care: do generalists and subspecialists differ?. Am J Public Health. 84;74(3):223-7. Article focuses on specific preventive measures only.
Dietrich A. J, O'Connor G. T, Keller A, Carney P. A, Levy D, Whaley F. S. Cancer: improving early detection and prevention. A community practice randomised trial. BMJ. 92;304(6828):687-91. Exposure not the PHE.
Dietrich, A. J., Tobin, J. N., Sox, C. H. et al. Cancer early-detection services in community health centers for the underserved. A randomized controlled trial. Arch Fam Med. 98. 7(4):320–7; discussion 328 Article focuses on specific preventive measures only
Doescher M. P, Saver B. G, Fiscella K, Franks P. Preventive care. J Gen Intern Med. 2004;19(6):632-7. Exposure not the PHE. [pmid: 15209601]. [pmcid: 1492377].
Drake, B. Predictors of preventive services provision among unsubstantiated cases.. Includes only subjects less than 18 years of age
Druss BG, Rohrbaugh RM Levinson CM Rosenheck RA Integrated medical care for patients with serious psychiatric illness: a randomized trial.. Exposure not the PHE
Druss B. G, Rosenheck R. A, Desai M. M, Perlin J. B. Quality of preventive medical care for patients with mental disorders. Med Care. 2002;40(2):129-36. Exposure not the PHE. [pmid: 11802085].
Duffy J. C. Multiphasic screening: a dynamic development in medicine. Arch Environ Health. 73;27(4):267-8. Exposure not the PHE. [pmid: 4728177].
Duncan D. F. The Peckham experiment: a pioneering exploration of wellness. Health Values. 85;9(5):40-3. No original data. [pmid: 10300468].
Dunn J. P, Hawkes R. Comparison of respondents and nonrespondents in a periodic health examination program to a mailed questionnaire. Am J Public Health Nations Health. 66;56(2):230-6. Does not apply to any of the key questions.
Durand Zaleski I, Zaleski S DEALEing and discounting: a simple way to compute the accrued cost of preventive strategies. Exposure not the PHE
Dykstra A. J. Early periodic screening, diagnosis, and treatment. Mich Nurse. 74;47(1):13-5. Includes only subjects less than 18 years of age. [pmid: 4596611].
Earle C. C, Burstein H. J, Winer E. P, Weeks J. C. Quality of non-breast cancer health maintenance among elderly breast cancer survivors. J Clin Oncol. 2003;21(8):1447-51. Exposure not the PHE. [pmid: 12697865].
Eaton C. B, Monroe A, McQuade W, Eimer M. M. Cholesterol testing and management: a national comparison of family physicians, general internists, and cardiologists. J Am Board Fam Pract. 98;11(3):180-6. Article focuses on specific preventive measures only.
Eccles M, Hawthorne G Whitty P Steen N Vanoli A Grimshaw J Wood L A randomised controlled trial of a patient based Diabetes Recall and Management System: the DREAM trial: a study protocol ISRCTN32042030.. Exposure not the PHE
Edwards, J. B. Partnerships for primary care in a changing health care system: a Tennessee nursing model.. Does not apply to any of the key questions
Edwards K. S. Medicine and politics. The annual checkup. Ohio State Med J. 83;79(1):23-67. Does not apply to any of the key questions. [pmid: 6828285].
Egwu I. N. Update: Primary care is not the same as primary health care, or is it?. Fam Community Health. 84;7(3):83-8. No original data. [pmid: 10318578].
Elinson J, Henshaw S. K, Cohen S. D. Response by a low income population to a multiphasic screening program: a sociological analysis. Prev Med. 76;5(3):414-24. Exposure not the PHE.
Ellenbecker, C. H., Wagner, L., and Cloutterbuck, J. Using insurance claims data and medical record reviews to assess the quality of medical care. J Healthc Qual. 97. 19(3):21–5, 28–31 Article focuses on specific preventive measures only
Ellsbury, K. E., Montano, D. E., and Parker, J. J. Jr Preventive services in a hybrid capitation and fee-for-service setting. J Fam Pract. 89. 28(5):540–3; discussion 543–4 Does not apply to any of the key questions
Elsom, K. A., Schor, S., Clark, T.W.., Elsom, K.O., and Hubbard, J. P. Periodic health examination. Nature and distribution of newly discovered disease in executives. JAMA. 60. 1725–10 Does not apply to any of the key questions
Elsom K. A, SoontT S, Potter R. H. P. An appraisal of the periodic health examination. Ind Med Surg. 56;25(8):367-71. Does not apply to any of the key questions.
Engberg M, Christensen B Karlsmose B Lous J Lauritzen T General health screenings to improve cardiovascular risk profiles: a randomized controlled trial in general practice with 5-year follow-up.. Exposure not the PHE
Erickson, K., Bradway, C., Beggs, C. M., Long, D. S., and Alford, D. M. Your turn. How do you carry out the Healthy People 2000 and the United States Preventive Services Task Force recommendations on immunizations, use of hormone replacement therapy, and prevention of incontinence in your older clients? Identify client information handouts you provide.. Does not apply to any of the key questions
Etter JF, Perneger TV Post-intervention effect of a computer tailored smoking cessation programme.. Exposure not the PHE
Evans, P. E. Accessing intravenous drug users via the health care system.. Does not apply to any of the key questions
Faust H. S. Strategies for obtaining preventive services reimbursement. Am J Prev Med. 90;6(4 Suppl):1-5. No original data. [pmid: 2242286].
Feldman R, Taller S. L. Multiphasic screening. JAMA. 73;223(5):559-60. Exposure not the PHE. [pmid: 4739152].
Felix-Aaron K, Moy E, Kang M, Patel M, Chesley F. D, Clancy C. Variation in quality of men's health care by race/ethnicity and social class. Med Care. 2005;43(3 Suppl):172-81. Exposure not the PHE.
Fielding J. E, Knight K. K, Goetzel R. Z, Laouri M. Utilization of preventive health services by an employed population. J Occup Med. 91;33(9):985-90. Exposure not the PHE.
Fink R, Shapiro S, Rosenberg C. Social research problems in studies involving multiphasic health testing. Health Serv Res. 72;7(4):314-21. Does not apply to any of the key questions.
Finkelstein EA, Troped PJ Will JC Palombo R Cost-effectiveness of a cardiovascular disease risk reduction program aimed at financially vulnerable women: the Massachusetts WISEWOMAN project.. Exposure not the PHE
Fiscella K, Goodwin M. A, Stange K. C. Does patient educational level affect office visits to family physicians?. J Natl Med Assoc. 2002;94(3):157-65. Does not apply to any of the key questions. [pmid: 11918385]. [pmcid: 2594098].
Flach S. D, McCoy K. D, Vaughn T. E, Ward M. M, Bootsmiller B. J, Doebbeling B. N. Does patient-centered care improve provision of preventive services?. J Gen Intern Med. 2004;19(10):1019-26. Exposure not the PHE. [pmid: 15482554]. [pmcid: 1492576].
Flagle D. Automated multiphasic health testing and services. Total systems analysis and design. Methods Inf Med. 71;10(4):201-6. Exposure not the PHE.
Fletcher, R. Review: hemoccult screening reduces death from colorectal cancer in average-risk patients greater than 50 years of age.. Does not apply to any of the key questions
Fletcher S. W. The periodic health examination and internal medicine: 1984. Ann Intern Med. 84;101(6):866-8. No original data. [pmid: 6497198].
Fletcher S. W, Dauphinee W. D. Should colorectal carcinoma be sought in periodic health examinations?--an approach to the evidence. Clin Invest Med. 81;4(1):23-31. No original data.
Fletcher S. W, Siscovick D. S, Inui T. S. Research on the periodic health examination: opportunities for the general internist. J Gen Intern Med. 86;1(4 Suppl):S45-9. No original data.
Flocke S. A, Gilchrist V. Physician and Patient Gender Concordance and the Delivery of Comprehensive Clinical Preventive Services. Med Care. 2005;43(5):486-492. Exposure not the PHE. [pmid: 15838414].
Flocke S. A, Stange K. C, Zyzanski S. J. The association of attributes of primary care with the delivery of clinical preventive services. Med Care. 98;36(8 Suppl):AS21-30. Article focuses on specific preventive measures only.
Flynn E. D. Barriers to utilization of multiphasic screening. The nurse's role. Occup Health Nurs. 69;17(7):19-21. Does not apply to any of the key questions.
Flynn E. D. Barriers to utilization of multiphasic screening: the nurse's role. J Occup Med. 69;11(7):361-3. Does not apply to any of the key questions.
Fontana S. A, Baumann L. C, Helberg C, Love R. R. The delivery of preventive services in primary care practices according to chronic disease status. Am J Public Health. 97;87(7):1190-6. Article focuses on specific preventive measures only.
Fox P. J, Breuer W, Wright J. A. Effects of a health promotion program on sustaining health behaviors in older adults. Am J Prev Med. 97;13(4):257-64. Does not apply to any of the key questions.
Frame P. S. Health maintenance in clinical practice: strategies and barriers. Am Fam Physician. 92;45(3):1192-200. No original data. [pmid: 1543104].
Frame P. S. Can computerized reminder systems have an impact on preventive services in practice?. J Gen Intern Med. 90;5(5 Suppl):S112-5. Exposure not the PHE.
FRANCO S. C. Multiphasic screening; occupational diseases; section on Industrial Medicine and Surgery, Medical Society of the State of New York. Ind Med Surg. 52;21(9):447-8. No original data.
FRANCO S. C. Meeting the shortcomings of the periodic physical examination. Ind Med Surg. 51;20(3):113-4. No original data. [pmid: 14813842].
FRANCO S. C. Periodic health examination of executives. Ind Med Surg. 50;19(5):213-8. Does not apply to any of the key questions. [pmid: 15412086].
FRANCO S. C, GERL A. J. The periodic health examination: a five-year survey. Ind Med Surg. 55;24(4):161-7. Does not apply to any of the key questions. [pmid: 14366758].
FRANCO, S. C., GERL, A. J., MURPHY, G. T. Periodic health examinations: a long term study, 1949-1959. J Occup Med. 61. 313–20 Does not apply to any of the key questions
Frank O, Litt J Beilby J Opportunistic electronic reminders. Improving performance of preventive care in general practice.. Article focuses on specific preventive measures only
Franklin R. R, Banta J. E. Systems analysis: motivational aspects of multiphasic screening. Clin Eng. 80;8(3):30-3. Exposure not the PHE. [pmid: 10247100].
Fretts, R. C., Rodman, G., Gome-Carrion, Y., Goldberg, R., Sachs, B. P., Myers, E., and Kessel, B. Preventive health services received by minority women aged 45-64 and the goals of Healthy People 2000.. Exposure not the PHE
Friedman C, Ahmed F, Franks A, Weatherup T, Manning M, Vance A, Thompson B. L. Association between health insurance coverage of office visit and cancer screening among women. Med Care. 2002;40(11):1060-7. Exposure not the PHE. [pmid: 12409851].
Friedman C, Brownson R. C, Peterson D. E, Wilkerson J. C. Physician advice to reduce chronic disease risk factors. Am J Prev Med. 94;10(6):367-71. Article focuses on specific preventive measures only.
Friedman G. D, Seltzer C. C, Siegelaub A. B, Feldman R, Collen M. F. Smoking among white, black, and yellow men and women. Kaiser-Permanente multiphasic health examination data, 1964-1968. Am J Epidemiol. 72;96(1):23-35. Does not apply to any of the key questions.
Froelicher ES, Sohn M Max W Bacchetti P Women's Initiative for Nonsmoking-VII: evaluation of health service utilization and costs among women smokers with cardiovascular disease.. Exposure not the PHE
Galen, R. S. Multiphasic screening and biochemical profiles: state of the art, 1975. Prog Clin Pathol. 75. 683–110 No original data
Gambino S. R. Multiphasic screening. J Med Soc N J. 69;66(3):122-4. Does not apply to any of the key questions. [pmid: 5252138].
Ganesan K, Teklehaimanot S, Akhtar A. J, Wijegunaratne J, Thadepalli K, Ganesan N. Racial differences in preventive practices of African-American and Hispanic women. J Am Geriatr Soc. 2003;51(4):515-8. Exposure not the PHE. [pmid: 12657071].
Gardner H. L. The gynecologist and the periodic checkup. Presidential address. Am J Obstet Gynecol. 66;95(1):1-4. Does not apply to any of the key questions.
Garfield S. R. Multiphasic health testing and medical care as a right. N Engl J Med. 70;283(20):1087-9. No original data. [pmid: 5470852].
Garr D. R, Ornstein S. M, Jenkins R. G, Zemp L. D. The effect of routine use of computer-generated preventive reminders in a clinical practice. Am J Prev Med. 93;9(1):55-61. Article focuses on specific preventive measures only.
Gary, A. Health promotion for special populations.. No original data
Gelman A. C. Automated multiphasic health testing. Public Health Rep. 70;85(4):361-73. Does not apply to any of the key questions. [pmid: 4985519].
Gemson D. H, Sloan R. P. Efficacy of computerized health risk appraisal as part of a periodic health examination at the worksite. Am J Health Promot. 95;9(6):462-6. Exposure not the PHE.
Gemson D. H, Ashford A. R, Dickey L. L, Raymore S. H, Roberts J. W, Ehrlich M. H, Foster B. G, Ganz M. L, Moon-Howard J, Field L. S, et al. Putting prevention into practice. Impact of a multifaceted physician education program on preventive services in the inner city. Arch Intern Med. 95;155(20):2210-6. Exposure not the PHE.
GETTING, V. A and LOMBARD, H. L. Multiphasic screening: what is it; what are the advantages?. Trans Annu Meet Natl Tuberc Assoc. 52. 48678–90 No original data
Gilbert F. I Jr. The Hawaii carrel--a modular approach to multiphasic screening. 1970. Hawaii Med J. 95;54(6):624-5. No original data. [pmid: 7642371].
Gilbert F. I Jr. Multiphasic screening cut down to size. 1968. Hawaii Med J. 95;54(6):623-4. No original data. [pmid: 7642370].
Gilbert F. I Jr, Nordyke R. A. Automated multiphasic health testing in multispecialty group practice. A laboratory for preventive medicine and health services research. Prev Med. 73;2(2):261-5. No original data.
Gill J. M, McClellan S. A. Improving preventive care for women: impact of a performance improvement program in a family practice office. Del Med J. 98;70(1):11-6. Article focuses on specific preventive measures only.
Gilliland F. D, Mahler R, Hunt W. C, Davis S. M. Preventive health care among rural American Indians in New Mexico. Prev Med. 99;28(2):194-202. Article focuses on specific preventive measures only.
Gitman L. Automated multiphasic health testing. The sociological implications. Hospitals. 71;45(5):63-8. Does not apply to any of the key questions.
Gjesdal K, Stromme J. H. Multiphasic screening programme for somatic diseases among elderly long-term psychiatric patients. Br J Psychiatry. 74;124(0):564-72. Does not apply to any of the key questions.
Glenn, J. The impact on interim payment system on New Mexico's home health care providers.. Does not apply to any of the key questions
Goebel LJ A peer review feedback method of promoting compliance with preventive care guidelines in a resident ambulatory care clinic.. Exposure not the PHE
Goetzel R Z The financial impact of health promotion and disease prevention programs--why is it so hard to prove value?. Exposure not the PHE
Goins K. V, Zapka J. G, Geiger A. M, Solberg L. I, Taplin S, Yood M. U, Gilbert J, Mouchawar J, Somkin C. P, Weinmann S. Implementation of systems strategies for breast and cervical cancer screening services in health maintenance organizations. Am J Manag Care. 2003;9(11):745-55. Exposure not the PHE. [pmid: 14626472].
Goldbloom R, Battista R. N. The periodic health examination: 1. Introduction. CMAJ. 88;138(7):617-8. No original data. [pmid: 3355930].
Goldbloom R. B. Getting the most out of the periodic “checkup”--the view from Canada. Pediatrics. 80;66(5):802-3. Includes only subjects less than 18 years of age.
Goodwin M. A, Zyzanski S. J, Zronek S, Ruhe M, Weyer S. M, Konrad N, Esola D, Stange K. C. A clinical trial of tailored office systems for preventive service delivery. The Study to Enhance Prevention by Understanding Practice (STEP-UP). Am J Prev Med. 2001;21(1):20-8. Exposure not the PHE. [pmid: 11418253].
Gordon R. E. Psychiatric screening through multiphasic health testing. Am J Psychiatry. 71;128(5):559-63. Exposure not the PHE. [pmid: 5114370].
Gotler, R. S., Williams, R. L., Flocke, S. A., Kikano, G. E., Stange, K. C. Improving patient care. Race and preventive services delivery.. No original data
Gottlieb N. H, Huang P. P, Blozis S. A, Guo J. L, Murphy Smith M. The impact of Put Prevention into Practice on selected clinical preventive services in five Texas sites. Am J Prev Med. 2001;21(1):35-40. Exposure not the PHE. [pmid: 11418255].
Graman H. B, Tufo H. M. Periodic health examinations: a systematic assessment of cost and yield. J Ambul Care Manage. 84;7(1):61-71. Does not apply to any of the key questions.
Griffith, H. M. The cost of clinical preventive services.. Does not apply to any of the key questions
Gross C. P, Mead L. A, Ford D. E, Klag M. J. Physician, heal Thyself? Regular source of care and use of preventive health services among physicians. Arch Intern Med. 2000;160(21):3209-14. Exposure not the PHE. [pmid: 11088080].
Gupta S, Roos LL Walld R Traverse D Dahl M Delivering equitable care: comparing preventive services in Manitoba. Exposure not the PHE
Hagdrup N. A, Simoes E. J, Brownson R. C. Health care coverage: traditional and preventive measures and associations with chronic disease risk factors. J Community Health. 97;22(5):387-99. Article focuses on specific preventive measures only.
Hahn D. L. Systematic cholesterol screening during acute care visits. J Am Board Fam Pract. 93;6(6):529-36. Article focuses on specific preventive measures only.
Halberstam M. J. The silent debits of multiphasic screening. N Engl J Med. 70;283(20):1114. No original data. [pmid: 5470865].
Hamm R, Kitts J. An approach to preventive periodic health examinations. Ala Med. 84;54(2):16-9. No original data. [pmid: 6475696].
Hampton T. R. Multiphasic screening: report on Naval Study 1975-1979. J R Nav Med Serv. 80;66(1):15-22. Does not apply to any of the key questions. [pmid: 7420304].
Harris R, Lohr K N Beck R Fink K Godley P Bunton A J Screening for prostate cancer. No original data
Harris J. S, Collins B, Majure I. L. The prevalence of health risks in an employed population. J Occup Med. 86;28(3):217-25. No eligible comparison group. [pmid: 3701468].
Hartmann K E, Hall S A Nanda K Boggess J F Zolnoun D Screening for cervical cancer. Does not apply to any of the key questions
Harvey P Preventive social health programs: are they Australia's answer to rising health care costs in rural communities?. No original data
HARVEY, J. C., REED, J. W., THAMER, M. A. Development of a multiphasic screening examination for medical care patients-I. Historical review and description of the examination. J Chronic Dis. 62. 15827–33 Does not apply to any of the key questions
Harwell T. S, McDowall J. M, Gohdes D, Helgerson S. D. Measuring and improving preventive care for patients with diabetes in primary health centers. Am J Med Qual. 2002;17(5):179-84. Exposure not the PHE. [pmid: 12412945].
Hawryluk O, Hagey A. Multiphasic screening in a military community. Mil Med. 80;145(8):539-41. Does not apply to any of the key questions. [pmid: 6774288].
Hay, W. I., Browne, G., Roberts, J., Jamieson, E. Prospective care of elderly patients in family practice. Part 3: Prevalence of unrecognized treatable health concerns. Can Fam Physician. 95. 411695-704, 1707–10 Exposure not the PHE
Hecker R. Medical practice and multiphasic screening. Med J Aust. 75;2(10):398-401. No original data. [pmid: 810645].
Heiser, N. A. and St. Peter, R. F., Quality management/improvement programs. Improving the delivery of clinical preventive services to women in managed care organizations: a case study analysis.. Exposure not the PHE
Helfand M, Mahon S Eden K Screening for skin cancer (Structured abstract). Does not apply to any of the key questions
Heller R. F, Chinn S, Pedoe H. D, Rose G. How well can we predict coronary heart disease? Findings in the United Kingdom Heart Disease Prevention Project. Br Med J (Clin Res Ed). 84;288(6428):1409-11. Article focuses on specific preventive measures only.
Hemming S. Alternative: providing preventive services for native people of Canada. Can Dent Hyg. 81;15(3):69-70. Exposure not the PHE. [pmid: 6945895].
Henderson J. T, Weisman C. S. Physician gender effects on preventive screening and counseling: an analysis of male and female patients' health care experiences. Med Care. 2001;39(12):1281-92. Exposure not the PHE. [pmid: 11717570].
Henderson J. T, Weisman C. S, Grason H. Are two doctors better than one? Women's physician use and appropriate care. Womens Health Issues. 2002;12(3):138-49. Exposure not the PHE. [pmid: 12015186].
Hendriksen C, Lund E Strømgård E Consequences of assessment and intervention among elderly people: a three year randomised controlled trial.. Exposure not the PHE
HERBOLSHEIMER, H., DEYOUNG, W., BRASWELL, H., and GILLOEGLY, O. Periodic health examination of university students. Results of reevaluation. Arch Environ Health. 63. 6573–8 Does not apply to any of the key questions
Hershey, C. O. and Karuza, J. Assessment of preventive health care: design considerations.. Exposure not the PHE
Hershey C. O, Karuza J, Szumigala J. Assessment of delivery of preventive health services. Am J Med Qual. 96;11(2):81-6. Exposure not the PHE. [pmid: 8704501].
Hiatt R. A, Fireman B. H. Smoking, menopause, and breast cancer. J Natl Cancer Inst. 86;76(5):833-8. Exposure not the PHE. [pmid: 3457970].
Hiatt R. A, Fireman B. H. Serum cholesterol and the incidence of cancer in a large cohort. J Chronic Dis. 86;39(11):861-70. Does not apply to any of the key questions.
Hinohara S, Takahashi T, Suzuki S, Matsuyama M, Kawamura N, Shinozuka T, Hata J, Tanabe T, Tamachi H, Goto Y. Diseases and cancer rate of AMHTS examines in the Tokai University Hospital. Tokai J Exp Clin Med. 81;6(3):267-74. Exposure not the PHE.
Hinohara S, Takahashi T, Uemura H, Noto T, Shinozuka T, Kinoshita H, Matsuyama M, Suzuki S, Osamura Y, Oogushi Y. Checkup interval and cancers in automated multiphasic health testing and services. Methods Inf Med. 93;32(3):192-4. Does not apply to any of the key questions.
Hinohara S, Takahashi T, Uemura H, Robinson D, Stehle G. The use of computerized risk assessment for personal instruction in the primary prevention of ischaemic heart disease in a Japanese Automated Multiphasic Health Testing and Services Center. Med Inform (Lond). 90;15(1):1-9. Exposure not the PHE.
Hoffman K, Remington P, Schell W. Preventive service delivery by primary care physicians, Wisconsin, 1995. Wis Med J. 96;95(10):717-9. Exposure not the PHE.
Hogg, W. E., Bass, M., Calonge, N., Crouch, H., and Satenstein, G. Randomized controlled study of customized preventive medicine reminder letters in a community practice. Can Fam Physician. 98. 4481–8 Exposure not the PHE
Holbrook A. Rule-based computerized reminders increased ordering of preventive services in an inpatient setting. ACP J Club. 2002;136(2). 74 Meeting abstract.
Holland B, Holland P. M, Hsieh R. K. Automated multiphasic health testing. Diagnostic and testing results obtained at the Health Evaluation Center. Public Health Service Hospital, Baltimore. Public Health Rep. 75;90(2):133-9. No eligible comparison group.
Holmboe, E. S., Van Hoof, T. J., Barr, J. K., Cohen, K. L., Reisine, S., Natale, K. M., Petrillo, M. k., and Meehan, T. P. A collaborative project to increase the use of preventive services by older adults enrolled in a risk-based Medicare managed care plan.. Exposure not the PHE
Holmes E. M, Pipes J. E, Bowden P. W. An analysis of the Richmond, Virginia, multiphasic health examination program. Trans Stud Coll Physicians Phila. 52;20(1):17-22. Meeting abstract.
Holmes J. S, Arispe I. E, Moy E. Heart disease and prevention: race and age differences in heart disease prevention, treatment, and mortality. Med Care. 2005;43(3 Suppl):133-41. Exposure not the PHE.
Hopkins R. S. Insurance coverage and usage of preventive health services. J Fla Med Assoc. 93;80(8):529-32. Article focuses on specific preventive measures only.
Hopkins S. C, Lenz E. R, Pontes N. M, Lin S. X, Mundinger M. O. Context of care or provider training: the impact on preventive screening practices. Prev Med. 2005;40(6):718-24. Exposure not the PHE. [pmid: 15850870].
Hornsby P. P, Reeve R. H, Gwaltney J. M Jr, Parsons B. D, Morse R. M. The University of Virginia health promotion and disease prevention program. Am J Prev Med. 97;13(1):36-44. No eligible comparison group.
Hourihan F, Krass I, Chen T. Rural community pharmacy: a feasible site for a health promotion and screening service for cardiovascular risk factors. Aust J Rural Health. 2003;11(1):28-35. Exposure not the PHE. [pmid: 12603444].
Howe H. F. Organization and operation of an occupational health program (revised edition)--Part III. XIII. Special programs in occupational medicine. Automated multiphasic health testing (AMHT) of employees. J Occup Med. 75;17(8):528-40. No original data.
Howe H. F. Application of automated multiphasic health testing in clinical medicine. The current state of the art. JAMA. 72;219(7):885-9. Exposure not the PHE.
Hsu H. Y, Gallinagh R. The relationships between health beliefs and utilization of free health examinations in older people living in a community setting in Taiwan. J Adv Nurs. 2001;35(6):864-73. Does not apply to any of the key questions. [pmid: 11555034].
Hueston W. J, Hubbard E. T. Preventive services for rural and urban African American adults. Arch Fam Med. 2000;9(3):263-6. Exposure not the PHE. [pmid: 10728114].
Hunter J. B, de Zapien J. G, Denman C. A, Moncada E, Papenfuss M, Wallace D, Giuliano A. R. Healthcare access and utilization among women 40 and older at the U.S.-Mexico border: predictors of a routine check-up. J Community Health. 2003;28(5):317-33. Does not apply to any of the key questions. [pmid: 14535598].
Huntley R. R. Role of automated multiphasic screening in future patterns of health care. Bull N Y Acad Med. 69;45(12):1383-7. Does not apply to any of the key questions.
HUNTLEY, R. R., Periodic health examinations in clinical practice. J Med Assoc State Ala. 63. 3320–5 Does not apply to any of the key questions
Hutchison B, Woodward C. A, Norman G. R, Abelson J, Brown J. A. Provision of preventive care to unannounced standardized patients. CMAJ. 98;158(2):185-93. Exposure not the PHE.
HUTCHISON, G. B. Evaluation of preventive services. J Chronic Dis. 60. 11497–508 Does not apply to any of the key questions
Iezzoni L. I, McCarthy E. P, Davis R. B, Harris-David L, O'Day B. Use of screening and preventive services among women with disabilities. Am J Med Qual. 2001;16(4):135-44. Exposure not the PHE. [pmid: 11477958].
Ingalls T. H, Gordon J. E. Periodic health examination 1900, 1965. Am J Med Sci. 66;251(3):333-50. Does not apply to any of the key questions. [pmid: 5905603].
Iniguez E, Palinkas L. A. Varieties of health services utilization by underserved Mexican American women. J Health Care Poor Underserved. 2003;14(1):52-69. Exposure not the PHE. [pmid: 12613068].
Inoue M, Maeda M, Ikeda M, Hayashida Y. Blood pressure variability at annual periodic health examination for employees and cardiovascular risk factors. Occup Med (Lond). 96;46(3):228-30. Article focuses on specific preventive measures only.
Ipsen J, Clark T. W, Elsom K. O, Roberts N. J. Diabetes and heart disease: periodic health examination programs. Am J Public Health Nations Health. 69;59(9):1595-612. Does not apply to any of the key questions.
Jackson, P. L. Primary care approaches. A systems approach to delivering clinical preventive services.. Includes only subjects less than 18 years of age
Jacobs E. A, Lauderdale D. S, Meltzer D, Shorey J. M, Levinson W, Thisted R. A. Impact of interpreter services on delivery of health care to limited-English-proficient patients. J Gen Intern Med. 2001;16(7):468-74. Exposure not the PHE. [pmid: 11520385]. [pmcid: 1495243].
Jamison H. C, McMillan R. S. An index of malocclusion for use in multiphasic screening and epidemiological investigations. Ala J Med Sci. 66;3(2):154-8. Does not apply to any of the key questions.
Janes G. R, Blackman D. K, Bolen J. C, Kamimoto L. A, Rhodes L, Caplan L. S, Nadel M. R, Tomar S. L, Lando J. F, Greby S. M, Singleton J. A, Strikas R. A, Wooten K. G. Surveillance for use of preventive health-care services by older adults, 1995-1997. MMWR CDC Surveill Summ. 99;48(8):51-88. Does not apply to any of the key questions.
Jelley D, Madeley R. J. Preventive health care for mothers and children. A study in Mozambique. J Trop Med Hyg. 83;86(6):229-36. Article focuses on specific preventive measures only.
Jenkins C. N, Le T, McPhee S. J, Stewart S, Ha N. T. Health care access and preventive care among Vietnamese immigrants: do traditional beliefs and practices pose barriers?. Soc Sci Med. 96;43(7):1049-56. Exposure not the PHE.
Jenkins R. G, Ornstein S. M. Preventive services in the primary care practices of the Practice Partner Research Network. Top Health Inf Manage. 2000;20(3):80-4. Does not apply to any of the key questions. [pmid: 10747438].
Jha P, Bangoura O Ranson K The cost-effectiveness of forty health interventions in Guinea. Exposure not the PHE
Johns MB, Hovell MF Drastal CA Lamke C Patrick K Promoting prevention services in primary care: a controlled trial.. Exposure not the PHE
Johns, D. B., Multiphasic screening. Trans Natl Saf Congr. 71. 1818–9 Does not apply to any of the key questions
Johns, D. B. Multiphasic screening. Trans Natl Saf Congr. 70. 1818–9 Does not apply to any of the key questions
JOHNSTON J. H. Values of periodic health examinations. Occup Health (Auckl). 53;13(4):53-4. Does not apply to any of the key questions. [pmid: 13037219].
Johnston M. V, Diab M. E, Chu B. C, Kirshblum S. Preventive services and health behaviors among people with spinal cord injury. J Spinal Cord Med. 2005;28(1):43-54. Exposure not the PHE. [pmid: 15832903].
JONES, W. T. Doubts on the periodic health examination. Trans Assoc Ind Med Off. 61. 1137–8 Does not apply to any of the key questions
Kane R L, Johnson P E Town R J Butler M Economic incentives for preventive care. No original data
Kaplan N. M. Hypertension: prevalence, risks, and effect of therapy. Ann Intern Med. 83;98(5 Pt 2):705-9. Article focuses on specific preventive measures only.
Kashima, S. Evaluating the effect of a preventive exam reminder letter sent to employees at an oil company.. No eligible comparison group
Katz R. Preventive services as insured employee benefits. J Occup Med. 78;20(4):273-4. Exposure not the PHE. [pmid: 641611].
Keller G. C. Cancer detection in the periodic physical examination. Cancer. 83;51(12 Suppl):2446-7. No original data. [pmid: 6850521].
Kelley C. R. The utilization of multiphasic screening in an ambulatory medical system. Bull N Y Acad Med. 73;49(5):406-14. Exposure not the PHE.
Kikano G. E, Goodwin M. A, Stange K. C. Physician employment status and practice patterns. J Fam Pract. 98;46(6):499-505. Article focuses on specific preventive measures only.
Kim C. S, Kristopaitis R. J, Stone E, Pelter M, Sandhu M, Weingarten S. R. Physician education and report cards: do they make the grade? results from a randomized controlled trial. Am J Med. 99;107(6):556-60. Exposure not the PHE.
King W. H, Owens L. F, Fadusko J. A. Coronary risk factors in flying personnel: a progress report. Aviat Space Environ Med. 77;48(2):162-3. Does not apply to any of the key questions.
Kinne S, Thompson B, Chrisman N. J, Hanley J. R. Community organization to enhance the delivery of preventive health services. Am J Prev Med. 89;5(4):225-9. No original data.
Kirby J. B, Kaneda T. Neighborhood socioeconomic disadvantage and access to health care. J Health Soc Behav. 2005;46(1):15-31. Exposure not the PHE. [pmid: 15869118].
Klatsky A. L, Friedman G. D, Siegelaub A. B, Gerard M. J. Alcohol consumption and blood pressure Kaiser-Permanente Multiphasic Health Examination data. N Engl J Med. 77;296(21):1194-200. Does not apply to any of the key questions.
Klatsky A. L, Friedman G. D, Siegelaub A. B, Gerard M. J. Alcohol consumption among white, black, or oriental men and women: Kaiser-Permanente multiphasic health examination data. Am J Epidemiol. 77;105(4):311-23. Does not apply to any of the key questions.
Kleiman M. B. Importance of a regular source of medical care among the elderly. J Am Geriatr Soc. 79;27(12):555-7. Exposure not the PHE. [pmid: 512284].
Knox E. G. Multiphasic screening. Lancet. 74;2(7894):1434-6. No original data. [pmid: 4140342].
Koch M. W. Taking care of ourselves: healthy communities.. No original data
Koepsell T, Reiber G, Simmons K. W. Behavioral risk factors and use of preventive services among veterans in Washington State. Prev Med. 2002;35(6):557-62. Does not apply to any of the key question. [pmid: 12460523].
Kondo H, Hashida M, Momotani H. Serum gamma-glutamyl transpeptidase as a diagnostic aid in the periodic health examination. Sangyo Igaku. 76;18(2):95-101. Does not apply to any of the key questions.
Koroukian S. M, Litaker D, Dor A, Cooper G. S. Use of Preventive Services by Medicare Fee-For-Service Beneficiaries: Does Spillover From Managed Care Matter?. Med Care. 2005;43(5):445-452. Exposure not the PHE. [pmid: 15838408].
Kottke T. E. Clinical preventive services: how should we define the indications?. Mayo Clin Proc. 90;65(6):899-902. Does not apply to any of the key questions.
Kremers H. M, Bidaut-Russell M, Scott C. G, Reinalda M. S, Zinsmeister A. R, Gabriel S. E. Preventive medical services among patients with rheumatoid arthritis. J Rheumatol. 2003;30(9):1940-7. Exposure not the PHE. [pmid: 12966594].
Kristofic J. D. Impact of multiphasic health testing on the future of traditional medical practice. Pa Med. 74;77(3):51-5. Does not apply to any of the key questions.
Krumholz H M, Weintraub W S Bradford W D Heidenreich P A Mark D B Paltiel AD Task force #2 - The cost of prevention: Can we afford it? Can we afford not to do it?. Article focuses on specific preventive measures only
KUH C. Lifelong adjustment of man and job; the possible role of multiphasic screening. Perm Found Med Bull. 52;10(1-4):301-5. No original data.
LaDou J. Multiphasic health testing in the clinic setting. Calif Med. 71;115(1):34-7. Exposure not the PHE. [pmid: 4935771].
LaDou J, Sherwood J. N, Hughes L. Multiphasic health testing. Benefit-cost analysis of high-volume and low-volume testing programs. J Occup Med. 75;17(8):495-501. Does not apply to any of the key questions.
Lafata J. E, Martin S, Morlock R, Divine G, Xi H. Provider type and the receipt of general and diabetes-related preventive health services among patients with diabetes. Med Care. 2001;39(5):491-9. Exposure not the PHE. [pmid: 11317097].
LAMAR, C. P. Search for cancer as a routine part of periodic physical examinations. Med Times. 60. 88285–9 No original data
Landon B. E, Zaslavsky A. M, Bernard S. L, Cioffi M. J, Cleary P. D. Comparison of performance of traditional Medicare vs Medicare managed care. JAMA. 2004;291(14):1744-52. Exposure not the PHE. [pmid: 15082702].
Lashof, J. C. MEDICHEK--the Illinois program of early periodic screening, diagnosis and treatment--what is it?. IMJ Ill Med J. 74. 145(3):268–9 passim Exposure not the PHE
Lave, J. R., Ives DG Traven ND Kuller LH Evaluation of a health promotion demonstration program for the rural elderly.. Exposure not the PHE
Lave J. R, Ives D. G, Traven N. D, Kuller L. H. Participation in health promotion programs by the rural elderly. Am J Prev Med. 95;11(1):46-53. Exposure not the PHE.
Law M. Health promotion and preventive services in primary care. Am J Prev Med. 88;4(4 Suppl):3-5. Does not apply to any of the key questions. [pmid: 3274750].
Lawthers A. G, Rozanski B. S, Nizankowski R, Rys A. Using patient surveys to measure the quality of outpatient care in Krakow, Poland. Int J Qual Health Care. 99;11(6):497-506. Exposure not the PHE.
Leatt, P. and Frank, J. Organizational issues related to integrating preventive services into primary care. Am J Prev Med. 88. 4(4 Suppl):127–37; discussion 138–40 No original data
Leers W. D, Kouroupis G. M, Dong A. Feasibility of routine testing for hepatitis B surface antigen in hospital employees and restriction of carriers. Can Med Assoc J. 76;115(10):995-8. Exposure not the PHE.
Lefkowitz A, Snow D. A, Cadigan D. A. Preventive care in a Veterans Administration continuity clinic. J Community Health. 90;15(1):7-18. Exposure not the PHE.
Lehman D. J Jr. Multiphasic health testing. JAMA. 77;237(20):2193-4. No original data. [pmid: 576902].
Lemelin J, Hogg W Baskerville N Evidence to action: a tailored multifaceted approach to changing family physician practice patterns and improving preventive care. [see comment]. Exposure not the PHE
Lemon S. C, Zapka J. G, Puleo E. Comprehensive cancer screening in a primary care population: Gender differences in the impact of ambulatory care system factors. J Ambul Care Manage. 2005;28(1):86-97. Does not apply to any of the key questions. [pmid: 15682966].
LENSON N. Analysis of a series of periodic physical examinations. N Engl J Med. 53;248(22):943. Does not apply to any of the key questions. [pmid: 13046649].
LEVIN M. L, BRIGHTMAN I. J. The place of multiphasic screening in the chronic disease program. N Y State J Med. 52;52(21):2600-4. No original data.
Levine R. S, Husaini B. A, Emerson J. S, Hull P. C, Briggs N. C, Moriarty C. J, Cain V. A. Using a nursing protocol to assure equitable delivery of cancer-related prevention services. Cell Mol Biol (Noisy-le-grand). 2003;49(8):1229-32. Exposure not the PHE. [pmid: 14983991].
Levy B. F. Multiphasic screening health examinations and practitioners. N Y State J Med. 69;69(15):2169. Does not apply to any of the key questions.
Lewis D. A, Giglio R. J. Tools to aid nurses in providing preventive services. Nurs Success Today. 86;3(3):9-15. No original data. [pmid: 3634917].
LINCOLN, T. A. and HURT, H. B. THERAPEUTIC VALUE OF THE PERIODIC HEALTH EXAMINATION. J Gnathol. 65. 46465–7 No original data
Litaker D, Flocke S. A, Frolkis J. P, Stange K. C. Physicians' attitudes and preventive care delivery: insights from the DOPC study. Prev Med. 2005;40(5):556-63. Exposure not the PHE. [pmid: 15749138].
Lobo CM, Frijling BD Hulscher ME Bernsen RM Braspenning JC Grol RP Prins A van der Wouden JC Improving quality of organizing cardiovascular preventive care in general practice by outreach visitors: a randomized controlled trial.. Exposure not the PHE
Logsdon D. N. Should health insurance cover preventive services?. Internist. 86;27(9):11-3. No original data. [pmid: 10278923].
Logsdon D. N, Lazaro C. M, Meier R. V. The feasibility of behavioral risk reduction in primary medical care. Am J Prev Med. 89;5(5):249-56. Exposure not the PHE.
Logsdon D. N, Rosen M. A, Demak M. M. The INSURE project on lifecycle preventive health services. Public Health Rep. 82;97(4):308-17. No original data.
Logsdon D. N, Rosen M. A, Thaddeus S, Lazaro C. M. Coverage of preventive services by preferred provider organizations. J Ambul Care Manage. 87;10(2):25-35. Does not apply to any of the key questions.
Long, P. H. annual physical examinations? Med Times. 64. 921199–200 Does not apply to any of the key questions
Lopez-de-Munain J, Torcal J, Lopez V, Garay J. Prevention in routine general practice: activity patterns and potential promoting factors. Prev Med. 2001;32(1):13-22. Exposure not the PHE. [pmid: 11162322].
Love RR, Baumann LC Brown RL Fontana SA Clark CC Sanner LA Davis JE Cancer prevention services and physician consensus in primary care group practices.. Exposure not the PHE
Love R. R, Davis J. E, Mundt M, Clark C. Health promotion and screening services reported by older adult patients of urban primary care physicians. J Fam Pract. 97;45(2):142-50. Article focuses on specific preventive measures only.
Lubin A. N, Young G. D Jr. Periodic physical examination--a large investment with a small return. Aerosp Med. 72;43(10):1141-3. Does not apply to any of the key questions.
Luckmann R, Melville S. K. Periodic health evaluation of adults: a survey of family physicians. J Fam Pract. 95;40(6):547-54. Does not apply to any of the key questions.
Luft H. S. Why do HMOs seem to provide more health maintenance services?. Milbank Mem Fund Q Health Soc. 78;56(2):140-68. Does not apply to any of the key questions.
Lusk S. L. Priorities for preventive services. AAOHN J. 2001;49(12):540-1. Exposure not the PHE. [pmid: 11806491].
Lusk, S. L. Linking practice & research. Priorities for preventive services.. No original data
Lynch FL, Whitlock EP Valanis BG Smith SK Cost-effectiveness of a tailored intervention to increase screening in HMO women overdue for Pap test and mammography services.. Article focuses on specific preventive measures only
MacDowell, M., Guo, L., and Short, A. Preventive health services use, lifestyle health behavior risks, and self-reported health status of women in Ohio by ethnicity and completed education status.. Exposure not the PHE
MacMillan H L, Patterson C J S Wathen C N with the Canadian Task Force on Preventive Health Care Screening for depression in primary care: updated recommendations from the Canadian Task Force on Preventive Health Care. No original data
Maddox, M.A. and Gibson, F. Affordable preventive health screening: mammograms for older African-American women... winner of the 1994 AJN/KNA writing contest.. Does not apply to any of the key questions
Madlon-Kay D. J. Improving the periodic health examination: use of a screening flow chart for patients and physicians. J Fam Pract. 87;25(5):470-3. Exposure not the PHE.
Madlon-Kay D. J, Harper P. G, Reif C. J. Use of a “Health Habits Questionnaire” to improve health promotion counseling. Arch Fam Med. 95;4(5):459-62. Exposure not the PHE.
Magnan S, Solberg L. I, Kottke T. E, Nelson A. F, Amundson G. M, Richards S, Reed M. K. IMPROVE: bridge over troubled waters. Jt Comm J Qual Improv. 98;24(10):566-78. Does not apply to any of the key questions.
Maibach E. W, Scutchfield F. D, Hovell M. F. A survey of primary-care physician preventive services: implications for smoking-cessation counseling. Patient Educ Couns. 84;6(3):113-5. Article focuses on specific preventive measures only.
Maier B. J. On the lead time of a periodic screening program. Methods Inf Med. 83;22(1):45-50. Does not apply to any of the key questions. [pmid: 6835094].
Mainous A. G 3rd, Hueston W. J, Love M. M, Griffith C. H. 3rd Access to care for the uninsured: is access to a physician enough?. Am J Public Health. 99;89(6):910-2. Article focuses on specific preventive measures only.
MAKSIM G. Periodic health examination campaign, a preview. Med Ann Dist Columbia. 51;20(12):666-7. No original data. [pmid: 14881817].
Mandelblatt J, Traxler M, Lakin P, Thomas L, Chauhan P, Matseoane S, Kanetsky P. A nurse practitioner intervention to increase breast and cervical cancer screening for poor, elderly black women. The Harlem Study Team. J Gen Intern Med. 93;8(4):173-8. Exposure not the PHE.
Mandelson M. T, Curry S. J, Anderson L. A, Nadel M. R, Lee N. C, Rutter C. M, LaCroix A. Z. Colorectal cancer screening participation by older women. Am J Prev Med. 2000;19(3):149-54. Exposure not the PHE. [pmid: 11020590].
Markarian S. An office-based guide to preventive services. Clin Prev Dent. 84;6(4):8-12. Does not apply to any of the key questions. [pmid: 6331959].
Marquis P. Preventive medicine: cheaper than a car... commentary on Filak AT Jr., Ricer JS, and Ricer RE. Lifetime costs for preventive medical services. J FAM PRACT. 1999;48:706-710. Exposure not the PHE. [pmid: 10498077].
Marsh G. M, Cassidy L. D. The Drake Health Registry Study: findings from fifteen years of continuous bladder cancer screening. Am J Ind Med. 2003;43(2):142-8. Exposure not the PHE. [pmid: 12541268].
MARTIN H. S. The periodic health examination. Burma Med J. 56;4(4):24-30. Does not apply to any of the key questions. [pmid: 13396616].
Martin P. D, Rhode P. C, Howe J. T, Brantley P. J. Primary care weight management counseling: physician and patient perspectives. J La State Med Soc. 2003;155(1):52-6. Exposure not the PHE. [pmid: 12656277].
Matsuoka K, Tanaka G, Etoh R, Horiuchi A. A 10-year follow-up study of per oral glucose tolerance at annual physical examinations. Tohoku J Exp Med. 83;141 Suppl:105-9. Article focuses on specific preventive measures only.
Mayer-Oakes S. A, Atchison K. A, Matthias R. E, De Jong F. J, Lubben J, Schweitzer S. O. Mammography use in older women with regular physicians: what are the predictors?. Am J Prev Med. 96;12(1):44-50. Article focuses on specific preventive measures only.
Mays G. P, Hesketh H. A, Ammerman A. S, Stockmyer C. K, Johnson T. L, Bayne-Smith M. Integrating preventive health services within community health centers: lessons from WISEWOMAN. J Womens Health (Larchmt). 2004;13(5):607-15. Exposure not the PHE. [pmid: 15257852].
McBride P, Underbakke G, Plane M. B, Massoth K, Brown R. L, Solberg L. I, Ellis L, Schrott H. G, Smith K, Swanson T, Spencer E, Pfeifer G, Knox A. Improving prevention systems in primary care practices: the Health Education and Research Trial (HEART). J Fam Pract. 2000;49(2):115-25. Exposure not the PHE. [pmid: 10718687].
McCabe, B. W., Bergman-Evans, B., and Grasser, C. M. Keeping a watchful eye. Receipt of preventive service screening recommendations by women in long-term care facilities. Geriatr Nurs. 98. 19(5):279–83; quiz 283 Article focuses on specific preventive measures only
McCall, T. Why you really must have an annual physical.. No original data
McCarty C. A, Chyou P. H, Greenlee R, McCarty D. J, Gunderson P, Reding D. Differences in preventive screening rates in Wisconsin farm and non-farm resident women. WMJ. 2003;102(5):22-6. Exposure not the PHE.
McCusker J, Morrow G The relationship of health locus of controls to preventive health behaviors and health beliefs.. Exposure not the PHE
McDonald CJ, Hui SL Smith DM Tierney WM Cohen SJ Weinberger M McCabe GP Reminders to physicians from an introspective computer medical record. A two-year randomized trial. Exposure not the PHE
McFall S. L, Solomon T. G, Smith D. W, Kelley M. Preventive services and satisfaction of Cherokee Nation patients. J Public Health Manag Pract. 2001;7(1):76-83. Exposure not the PHE. [pmid: 11141626].
MCGEE L. C. Periodic health examinations in industry. Del Med J. 53;25(1):1-8. No original data. [pmid: 13020405].
McGuire, S. and Nalle, M. Healthy People initiative: an introduction... part 1.. No original data
McIntosh I. B, Power K. G. Elderly people's views of an annual screening assessment. Br J Gen Pract. 93;43(370):189-92. Exposure not the PHE. [pmid: 8347385].
McIsaac, W. J., Fuller-Thomson, E., and Talbot, Y. Does having regular care by a family physician improve preventive care?. Can Fam Physician. 2001. 4770–6 Exposure not the PHE
McNamara J. J. Early and periodic screening. Medi-Screen program structure and standard setting. West J Med. 74;120(3):263-6. Article focuses on specific preventive measures only.
Mead V. P, Rhyne R. L, Wiese W. H, Lambert L, Skipper B. Impact of environmental patient education on preventive medicine practices. J Fam Pract. 95;40(4):363-9. Exposure not the PHE.
Mehta B. R. Non-automated multiphasic health examination using existing facilities. Hawaii Med J. 74;33(9):336-9. Does not apply to any of the key questions.
Melnikow J, Kohatsu N. D, Chan B. K. Put prevention into practice: a controlled evaluation. Am J Public Health. 2000;90(10):1622-5. Exposure not the PHE. [pmid: 11030000]. [pmcid: 1446373].
Meng Q, Liu X, Shi J. Comparing the services and quality of private and public clinics in rural China. Health Policy Plan. 2000;15(4):349-56. Exposure not the PHE. [pmid: 11124237].
Michalek A. M, Wende K, Cummings K. M, Aungst C. W. Experiences with multiphasic screening for cancer. J Cancer Educ. 88;3(3):187-92. No eligible comparison group.
Miller C. E. Advances in multiphasic screening and testing. Calif Med. 67;107(5):385-90. Does not apply to any of the key questions. [pmid: 6083242].
Miller, D. G. The yield of new problems found during periodic health examinations of impoverished patients. Ohio State Med J. 85. 81(9):660, 662-5 Does not apply to any of the key questions
Mills, P. K. Overview.. Exposure not the PHE
Montgomery R. L, Singman D. Multiphasic screening. Hospitals. 70;44(6):71-4. Exposure not the PHE. [pmid: 5416385].
Moore, L. J. Checkup doubts... for symptom-free adults, an annual physical is largely a waste of time.. No original data
Morales L. S, Rogowski J, Freedman V. A, Wickstrom S. L, Adams J. L, Escarce J. J. Sociodemographic differences in use of preventive services by women enrolled in Medicare+Choice plans. Prev Med. 2004;39(4):738-45. Exposure not the PHE. [pmid: 15351540].
Morgan, J., Vang, A., and Wong, W. PSA screening recommendations -- why experts disagree.. No original data
Morgan, M. M., Goodson, J., and Barnett, G. O. Long-term changes in compliance with clinical guidelines through computer-based reminders. Proc AMIA Symp. 98. 493–7 Article focuses on specific preventive measures only
Morgan W. K. Admission multiphasic screening. Lancet. 77;1(8003):142. No original data. [pmid: 64673].
Morgenstern, N. L. Automated multiphasic screening and periodic health examinations. J Iowa Med Soc. 69. 59(5):407–13 passim Does not apply to any of the key questions
MORHOUS E. J, BAKER J. P, BALLOU H. C, CRUMPACKER E. L. Periodic health examinations. Ann Intern Med. 57;46(4):744-9. No original data. [pmid: 13411883].
Morrison B. The periodic health examination: 3. Breast cancer. CMAJ. 86;134(7):727-9. No original data. [pmid: 3948090].
Moskowitz M. Clinical examination of the breasts by nonphysicians: a viable screening option?. Cancer. 79;44(1):311-4. Exposure not the PHE. [pmid: 455257].
Mukohara, K. Public expectation for annual physical examinations. Ann Intern Med. 2002. 137(9):773–4; author reply 773–4 No original data
Muldoon J. T, Schootman M, Morton R. F. Utilization of cancer early detection services among farm and rural nonfarm adults in Iowa. J Rural Health. 96;12(4 Suppl):321-31. Exposure not the PHE.
Murphy, D. J., Gross, R., and Buchanan, J. Computerized reminders for five preventive screening tests: generation of patient-specific letters incorporating physician preferences. Proc AMIA Symp. 2000. 600–4 Exposure not the PHE
Murphy-Smith M, Meyer B, Hitt J, Taylor-Seehafer M. A, Tyler D. O. Put Prevention into Practice implementation model: translating practice into theory. J Public Health Manag Pract. 2004;10(2):109-15. Exposure not the PHE. [pmid: 14967977].
Musich S, Ignaczak A, McDonald T, Hirschland D, Edington D. W. Self-reported utilization of preventive health services by retired employees age 65 and older. J Am Geriatr Soc. 2001;49(12):1665-72. Exposure not the PHE. [pmid: 11844001].
Muto T, Yamauchi K Evaluation of a multicomponent workplace health promotion program conducted in Japan for improving employees' cardiovascular disease risk factors.. Exposure not the PHE
Muto T, Hsieh S. D, Sakurai Y. Status of health promotion programme implementation in small-scale enterprises in Japan. Occup Med (Lond). 99;49(2):65-70. Does not apply to any of the key questions.
Nagao T, Warnakulasuriya S. Annual screening for oral cancer detection. Cancer Detect Prev. 2003;27(5):333-7. Exposure not the PHE. [pmid: 14585319].
NAHUM, L. H. Are periodic health examinations worthwhile?. Conn Med. 63. 2790–2 No original data
Nilasena, D. S. and Lincoln, M. J. A computer-generated reminder system improves physician compliance with diabetes preventive care guidelines. Proc Annu Symp Comput Appl Med Care. 95. 640–5 Exposure not the PHE
O'Malley A. S, Mandelblatt J. Delivery of preventive services for low-income persons over age 50: a comparison of community health clinics to private doctors' offices. J Community Health. 2003;28(3):185-97. Exposure not the PHE. [pmid: 12713069].
O'Malley A. S, Sheppard V. B, Schwartz M, Mandelblatt J. The role of trust in use of preventive services among low-income African-American women. Prev Med. 2004;38(6):777-85. Exposure not the PHE. [pmid: 15193898].
Oboler S. K, Prochazka A. V, Gonzales R, Xu S, Anderson R. J. Public expectations and attitudes for annual physical examinations and testing. Ann Intern Med. 2002;136(9):652-9. No original data. [pmid: 11992300].
Okoro C. A, Strine T. W, Young S. L, Balluz L. S, Mokdad A. H. Access to health care among older adults and receipt of preventive services. Results from the Behavioral Risk Factor Surveillance System, 2002. Prev Med. 2005;40(3):337-43. Exposure not the PHE. [pmid: 15533548].
Olsen D. M, Kane R. L, Proctor P. H. A controlled trial of multiphasic screening. N Engl J Med. 76;294(17):925-30. Exposure not the PHE. [pmid: 1256483].
Orford R. R, Carter E. T. Preemployment and periodic physical examination of airline pilots at the Mayo clinic, 1939-1974. Aviat Space Environ Med. 76;47(2):180-4. Does not apply to any of the key questions.
Orme Johnson D W, Herron R E An innovative approach to reducing medical care utilization and expenditures. Exposure not the PHE
Ornstein S. M, Garr D. R, Jenkins R. G, Musham C, Hamadeh G, Lancaster C. Implementation and evaluation of a computer-based preventive services system. Fam Med. 95;27(4):260-6. Exposure not the PHE.
Ornstein S. M, Garr D. R, Jenkins R. G, Rust P. F, Arnon A. Computer-generated physician and patient reminders. Tools to improve population adherence to selected preventive services. J Fam Pract. 91;32(1):82-90. Article focuses on specific preventive measures only.
Orso C. L. Delivering ambulatory health care: the successful experience of an urban neighborhood health center. Med Care. 79;17(2):111-26. Does not apply to any of the key questions.
Ozminkowski R. J, Dunn R. L, Goetzel R. Z, Cantor R. I, Murnane J, Harrison M. A return on investment evaluation of the Citibank, N.A., health management program. Am J Health Promot. 99;14(1):31-43. Exposure not the PHE.
PAGE R. C. An objective appraisal of periodic health examinations. Ind Med Surg. 53;22(11):510-3. Does not apply to any of the key questions. [pmid: 13108314].
Palda V A, Van Spall H G C with the Canadian Task Force on Preventive Health Care Screening for lung cancer: updated recommendations from the Canadian Task Force on Preventive Health Care. No original data
Palmer K. Preventive medicine and screening II. Practitioner. 89;233(1480):1611-2. Does not apply to any of the key questions. [pmid: 2622851].
Parchman M. L, Burge S. K. The patient-physician relationship, primary care attributes, and preventive services. Fam Med. 2004;36(1):22-7. Exposure not the PHE. [pmid: 14710325].
Park G. HMSA's HealthPass--a strategy for delivery of preventive services. Hawaii Med J. 95;54(8):697-703. No eligible comparison group. [pmid: 7558803].
PATRIE, L. E. A multiphasic screening project on the Pine Ridge Indian Reservation. J Lancet. 62. 82511–4 Exposure not the PHE
Paukert J. L, Chumley-Jones H. S, Littlefield J. H. Do peer chart audits improve residents' performance in providing preventive care?. Acad Med. 2003;78(10 Suppl):S39-41. Exposure not the PHE. [pmid: 14557091].
Pels, R. J., Bor, D. H., and Lawrence, R. S. Decision making for introducing clinical preventive services. Annu Rev Public Health. 89. 10363–83 No original data
Perkoff, G. T., Kahn, L., and Haas, P. J. Cost of medical care in an experimental study of prepaid group and fee for service practice. Trans Assoc Am Physicians. 75. 88271–7 Exposure not the PHE
Phillips T. J. The tools of preventive medicine in family practice. The annual physical examination?. Postgrad Med. 72;51(1):154-8. Does not apply to any of the key questions.
Pieper, B. and DiNardo, E. Health maintenance in a primary care clinic for urban, indigent adults.. Exposure not the PHE
Pignone M P, Philips C J Lannon C M Mulrow C D Teutsch S M Lohr K N Whitener B L Screening for lipid disorders (Structured abstract). No original data
Pinkerton R. E, Jackson M. G, Yankaskas B. C, Berger A. Preemployment multiphasic screening in an urban manpower training program. J Occup Med. 83;25(2):112-4. Does not apply to any of the key questions.
Pol L. G, Rouse J, Zyzanski S, Rasmussen D, Crabtree B. Rural, urban and suburban comparisons of preventive services in family practice clinics. J Rural Health. 2001;17(2):114-21. Exposure not the PHE. [pmid: 11573461].
Pollard A. H. The economics of multiphasic screening. Med J Aust. 72;2(18):1025-8. No original data. [pmid: 4665224].
Pommerenke F. A, Dietrich A. Improving and maintaining preventive services. Part 1: Applying the patient path model. J Fam Pract. 92;34(1):86-91. No original data.
Potosky A. L, Breen N, Graubard B. I, Parsons P. E. The association between health care coverage and the use of cancer screening tests. Results from the 1992 National Health Interview Survey. Med Care. 98;36(3):257-70. Article focuses on specific preventive measures only.
Powell-Griner E, Bolen J, Bland S. Health care coverage and use of preventive services among the near elderly in the United States. Am J Public Health. 99;89(6):882-6. Does not apply to any of the key questions.
Preisser J. S, Cohen S. J, Wofford J. L, Moran W. P, Shelton B. J, McClatchey M. W, Wolfe P. Physician and patient predictors of health maintenance visits. Arch Fam Med. 98;7(4):346-51. Does not apply to any of the key questions.
Pringle M, Robins S, Brown G. Computer assisted screening: effect on the patient and his consultation. Br Med J (Clin Res Ed). 85;290(6483):1709-12. Does not apply to any of the key questions.
Proger, S. Diagnostic imperatives in internal medicine. The timely detection of treatable disease. The periodic health examination. J Maine Med Assoc. 80. 71(2): 50-2, 54, 59 No original data
Pullen C, Fiandt K, Walker S. N. Determinants of preventive services utilization in rural older women. J Gerontol Nurs. 2001;27(1):40-51. Exposure not the PHE.
Quenan L, Remington P, Gohre F, Zapp P. The Wisconsin Collaborative Diabetes Quality Improvement Project. WMJ. 2000;99(3):48-52. Exposure not the PHE.
Quinones M. A, Cinotti A. A. Multiphasic screening in Newark. J Med Soc N J. 75;72(1):31-3. No eligible comparison group. [pmid: 1054092].
Rabin D. L, Schach E. Medicaid, morbidity, and physician use. Med Care. 75;13(1):68-78. Does not apply to any of the key questions. [pmid: 803293].
Rabiner D. J, Branch L. G, Sullivan R. J. The receipt of prevention services by veterans using VA versus non-VA facilities. Prev Med. 98;27(5 Pt 1):690-6. Article focuses on specific preventive measures only.
Rabiner D. J, Branch L. G, Sullivan R. J Jr. Patient factors related to the odds of receiving prevention services in Veterans Health Administration medical centers. Am J Manag Care. 99;5(9):1153-60. Exposure not the PHE.
Rafferty M. Prevention services in primary care: taking time, setting priorities. West J Med. 98;169(5):269-75. Article focuses on specific preventive measures only.
Rakowski, W., Clark, M. A., and Ehrich, B. Smoking and cancer screening for women ages 42-75: associations in the 1990-1994 National Health Interview Surveys.. Exposure not the PHE
Rawson G. Multiphasic screening--definition and assessment. Med J Aust. 72;2(9):497-504. No original data. [pmid: 5083603].
Reddick A. An evaluation of the IFA-GC procedure in a low risk population. Health Lab Sci. 75;12(3):208-14. Exposure not the PHE. [pmid: 829827].
Redeker, N. S. Putting prevention into nursing practice.. No original data
Reece R. L. Using a computer to interpret multiphasic screening results. Geriatrics. 74;29(1):51-9. Exposure not the PHE. [pmid: 4586852].
Reisinger A. L, Sisk J. E. Preventive service use and Medicaid managed care in New York City. Am J Manag Care. 2000;6(1):45-51. Exposure not the PHE. [pmid: 11009746].
Ren A, Okubo T, Takahashi K. Comprehensive periodic health examination: impact on health care utilisation and costs in a working population in Japan. J Epidemiol Community Health. 94;48(5):476-81. No eligible comparison group.
REVENO W. S. The value of the periodic health examination. J Mich State Med Soc. 53;52(5):516-9. Does not apply to any of the key questions. [pmid: 13053173].
Richards E. P 3rd, Rathbun K. C. Effective initial screening. Trial. 80;16(5):45-9. 74 Exposure not the PHE. [pmid: 10247767].
ROBERTS, N. J. AN EVALUATION OF THE PERIODIC HEALTH EXAMINATION. A PREFACE. Ann Intern Med. 64. 61997–8 Does not apply to any of the key questions
Robinson, B. E. Progress in prevention... the Prevention for Elderly Persons (PEP) Program: a model of municipal and academic partnership to meet the needs of older persons for preventive services.. No original data
Rodney M. B. Multiphasic health testing and group practice. J Natl Med Assoc. 68;60(4):282-6. Does not apply to any of the key questions. [pmid: 5661196].
Rodnick J. E, Bubb K. Patient education and multiphasic screening: it can change behavior. J Fam Pract. 78;6(3):599-607. Exposure not the PHE. [pmid: 632772].
Roh J. Overall view of occupational health services in Korea. Asia Pac J Public Health. 2000;12(Suppl):S41-4. Exposure not the PHE. [pmid: 11338736].
Romm F. J. The periodic health examination in a family practice center: use, content, and results. Fam Pract Res J. 87;7(2):69-77. No eligible comparison group.
Romm, F. J. Periodic health examination: effect of costs on patient expectations. South Med J. 85. 78(11):1330–2, 1340 Does not apply to any of the key questions
Romm F. J. Patients' expectations of periodic health examinations. J Fam Pract. 84;19(2):191-5. Does not apply to any of the key questions. [pmid: 6747560].
Rose S. D. The periodic health examination. Prim Care. 80;7(4):653-65. No original data. [pmid: 6782598].
Rosen M. A, Logsdon D. N, Demak M. M. Prevention and health promotion in primary care: baseline results on physicians from the INSURE Project on Lifecycle Preventive Health Services. Prev Med. 84;13(5):535-48. Does not apply to any of the key questions.
ROSENTHAL T, VANDOW J. E. House-to-house serologic survey with multiphasic screening. Public Health Rep. 57;72(11):969-75. Exposure not the PHE.
Rosin A. J, Galinsky D. Health testing in the elderly by the multiphasic method. Gerontol Clin (Basel). 75;17(2):80-8. Does not apply to any of the key questions.
Rosser W. W, McDowell I, Newell C. Use of reminders for preventive procedures in family medicine. CMAJ. 91;145(7):807-14. Exposure not the PHE. [pmid: 1913409].
Rothbart P. L. Liability of corporate physicians in conducting preemployment and annual physical examinations. J Leg Med. 85;6(4):477-87. Does not apply to any of the key questions.
Rountree P, Frasier T. S. Multiphasic screening in an indigent population. J Ark Med Soc. 75;72(3):128-9. No eligible comparison group. [pmid: 125738].
Rowe I. L, Larsen L. H. Evaluation of automated multiphasic health testing in the survey of the north-west region of Melbourne. Med J Aust. 79;2(6):320-4. Does not apply to any of the key questions.
Ruhe M. C, Weyer S. M, Zronek S, Wilkinson A, Wilkinson P. S, Stange K. C. Facilitating practice change: lessons from the STEP-UP clinical trial. Prev Med. 2005;40(6):729-34. Exposure not the PHE. [pmid: 15850872].
Ryan J. G. Periodic health examination of the elderly. Aust Fam Physician. 78;7(3):285-90. Does not apply to any of the key questions. [pmid: 637783].
Salonen JT, Puska P Kottke TE Tuomilehto J Changes in smoking, serum cholesterol and blood pressure levels during a community-based cardiovascular disease prevention program - the North Karelia Project. Does not apply to any of the key questions
Sambamoorthi U, McAlpine D. D. Racial, ethnic, socioeconomic, and access disparities in the use of preventive services among women. Prev Med. 2003;37(5):475-84. Exposure not the PHE. [pmid: 14572431].
SAMIS S. M. Multiphasic screening may be the keystone of preventive medicine. Mod Hosp. 51;77(5):94-102. No original data. [pmid: 14890645].
Sarin R. K. Periodic health examination. J Indian Med Assoc. 66;47(4):161-2. No original data. [pmid: 5911063].
Sasamori, N. National statistics on multiphasic health testing (Human Dock, AMHTS)--with special reference to annual changes in the last eight years. Jpn Hosp. 93. 1285–96 Exposure not the PHE
Sasamori, N. National statistics on multiphasic health testing (human dock and AMHTS)--especially for the annual-course change during the last five years. Jpn Hosp. 90. 983–95 Does not apply to any of the key questions
SCHEELE L. A. Current experience in multiphasic health examination; orientation and background. Am J Public Health. 51;41(6):635-9. No original data.
Schellhase K. G, Koepsell T. D, Norris T. E. Providers' reactions to an automated health maintenance reminder system incorporated into the patient's electronic medical record. J Am Board Fam Pract. 2003;16(4):312-7. Exposure not the PHE. [pmid: 12949032].
SCHENTHAL J. E. Multiphasic screening of the well patient. Twelve-year experience of the Tulane University Cancer Detection Clinic. JAMA. 60:1721-4. Does not apply to any of the key questions.
SCHNEIDER, R. F. A review of the value of periodic health examinations. Trans Assoc Ind Med Off. 61. 1127–36 No original data
Schneider W. J. A worksite hypertension control program for hospital employees utilizing repetitive monitoring. J Occup Med. 81;23(2):91-3. Article focuses on specific preventive measures only.
Scholle S. H, Agatisa P. K, Krohn M. A, Johnson J, McLaughlin M. K. Locating a health advocate in a private obstetrics/gynecology office increases patient's receipt of preventive recommendations. J Womens Health Gend Based Med. 2000;9(2):161-5. Does not apply to any of the key questions. [pmid: 10746519].
Scholle S. H, Chang J. C, Harman J, McNeil M. Trends in women's health services by type of physician seen: data from the 1985 and 1997-98 NAMCS. Womens Health Issues. 2002;12(4):165-77. Does not apply to any of the key questions. [pmid: 12093581].
Scholle S. H, Chang J, Harman J, McNeil M. Characteristics of patients seen and services provided in primary care visits in obstetrics/gynecology: data from NAMCS and NHAMCS. Am J Obstet Gynecol. 2004;190(4):1119-27. Exposure not the PHE. [pmid: 15118652].
SCHOR, S. S., CLARK, T. W., PARKHURST, L. W., BAKER, J. P., and ELSOM, K. A. AN EVALUATION OF THE PERIODIC HEALTH EXAMINATION. THE FINDINGS IN 350 EXAMINEES WHO DIED. Ann Intern Med. 64. 61999–1005 Does not apply to any of the key questions
SCHOR, S. S., ELSOM, K. A., ELSOM, K. O., and DUNN, J. P. AN EVALUATION OF THE PERIODIC HEALTH EXAMINATION: A STUDY OF FACTORS DISCRIMINATING BETWEEN SURVIVAL AND DEATH FROM CORONARY HEART DISEASE. Ann Intern Med. 64. 611006–14 Does not apply to any of the key questions
Schrager S, Plane M. B, Mundt M. P, Stauffacher E. A. Osteoporosis prevention counseling during health maintenance examinations. J Fam Pract. 2000;49(12):1099-103. Exposure not the PHE. [pmid: 11132059].
Schrijnemaekers VJ, Haveman MJ Effects of preventive outpatient geriatric assessment: short-term results of a randomized controlled study.. Exposure not the PHE
Schussler, T. and Flynn, M. L. Lowering triglyceride values in an occupational setting. Urban Health. 82. 11(1):26–7, 46–7 Exposure not the PHE
Schwartz J. S, Lewis C. E, Clancy C, Kinosian M. S, Radany M. H, Koplan J. P. Internists' practices in health promotion and disease prevention. A survey. Ann Intern Med. 91;114(1):46-53. Article focuses on specific preventive measures only.
Schweitzer S. O, Atchison K. A, Lubben J. E, Mayer-Oakes S. A, De Jong F. J, Matthias R. E. Health promotion and disease prevention for older adults: opportunity for change or preaching to the converted?. Am J Prev Med. 94;10(4):223-9. Does not apply to any of the key questions.
Secker-Walker R. H, Flynn B. S, Solomon L. J, Vacek P. M, Bronson D. L. Predictors of smoking behavior change 6 and 18 months after individual counseling during periodic health examinations. Prev Med. 90;19(6):675-85. Does not apply to any of the key questions.
Selby JV, Friedman GD Collen MF Sigmoidoscopy and mortality from colorectal cancer: the Kaiser Permanente Multiphasic Evaluation Study.. Article focuses on specific preventive measures only
Selinger H. A, Gregorio D. I, Strelez L. A. Practices around periodic cancer screening by physicians in primary care specialties. Conn Med. 91;55(8):443-8. Exposure not the PHE.
SERBY J. L. Periodic health examinations on international basis. Miss Valley Med J. 57;79(5):205-10. Exposure not the PHE. [pmid: 13464710].
Shapiro S. Automated multiphasic health testing. Efficacy of the concept. Hospitals. 71;45(5):45-8. Exposure not the PHE. [pmid: 5546689].
Shapiro S, Fink R, Rosenberg C. A program to measure the impact of multiphasic health testing on health differentials between poverty and nonpoverty groups. Med Care. 72;10(3):207-14. Exposure not the PHE.
Sheahan S. L. Documentation of health risks and health promotion counseling by emergency department nurse practitioners and physicians. J Nurs Scholarsh. 2000;32(3):245-50. Exposure not the PHE. [pmid: 12462818].
SHEPS C. G. The concept of multiphasic screening for chronic diseases. N C Med J. 50;11(11):626-30. No original data. [pmid: 14785864].
Shi L, Stevens G. D. Vulnerability and the receipt of recommended preventive services: the influence of multiple risk factors. Med Care. 2005;43(2):193-8. Exposure not the PHE. [pmid: 15655434].
SHILLITO F. H. Periodic health examinations. Ann Intern Med. 53;39(1):7-14. Does not apply to any of the key questions. [pmid: 13065984].
Shindell S. Multiphasic screening. N Engl J Med. 69;281(4):222-3. Does not apply to any of the key questions. [pmid: 5790516].
Siegel G. S. An American dilemma--the periodic health examination. Arch Environ Health. 66;13(3):292-5. No original data. [pmid: 5922231].
Simons L. A, Jones A. S. Coronary risk factor screening and long-term follow up: year 1 of the Sydney Coronary Heart Disease Prevention Programme. Med J Aust. 78;2(10):455-8. Exposure not the PHE.
Sirovich B. E, Schwartz L. M, Woloshin S. Screening men for prostate and colorectal cancer in the United States: does practice reflect the evidence?. JAMA. 2003;289(11):1414-20. Exposure not the PHE. [pmid: 12636464].
Skoulas A, Conlon D. Two-step electrocardiogram for chest pain reported on multiphasic screening. J Electrocardiol. 75;8(1):49-52. Does not apply to any of the key questions.
SMILLIE W. G. “Multiphasic” screening tests. J Am Med Assoc. 51;145(16):1254-6. No original data. [pmid: 14813916].
SMILLIE W. G, HAHN R. G. Inherent inadequacies of multiphasic screening. N Y State J Med. 52;52(21):2610-3. No original data. [pmid: 13002860].
Smith E. F. The utilization of multiphasic screening in Public Health Centers. J Occup Med. 69;11(7):364-8. Does not apply to any of the key questions.
Smith H. E, Herbert C. P. Preventive practice among primary care physicians in British Columbia: relation to recommendations of the Canadian Task Force on the Periodic Health Examination. CMAJ. 93;149(12):1795-800. Article focuses on specific preventive measures only.
Smith J. Health education. 1. Prevention by example. Nurs Mirror. 84;159(13):17-8. No original data. [pmid: 6567917].
Smith M. M, Meyer B, Goodson P, Gottlieb N. H, Huang P. Chart documentation of clinical preventive services at 9 Texas clinics. Tex Med. 99;95(8):56-62. Article focuses on specific preventive measures only.
Smith R. A, Wender R. C. Cancer screening and the periodic health examination. Cancer. 2004;100(8):1553-7. No original data. [pmid: 15073841].
SODEMAN W. A. An evaluation of some procedures used in multiphasic screening. Can J Public Health. 51;42(2):43-51. Does not apply to any of the key questions.
Solanki G, Schauffler H. H. Cost-sharing and the utilization of clinical preventive services. Am J Prev Med. 99;17(2):127-33. Exposure not the PHE.
Solanki G, Schauffler H. H, Miller L. S. The direct and indirect effects of cost-sharing on the use of preventive services. Health Serv Res. 2000;34(6):1331-50. Exposure not the PHE. [pmid: 10654834]. [pmcid: 1089084].
Solberg LI, Kottke TE Brekke ML Conn SA Magnan S Amundson G The case of the missing clinical preventive services systems.. Exposure not the PHE
Solberg L. I, Isham G, Kottke T. E, Magnan S, Nelson A, Reed M, Richards S. Competing HMOs collaborate to improve preventive services. Jt Comm J Qual Improv. 95;21(11):600-10. Exposure not the PHE.
Solberg L. I, Kottke T. E, Brekke M. L. Variation in clinical preventive services. Eff Clin Pract. 2001;4(3):121-6. Exposure not the PHE. [pmid: 11434075].
Solberg L. I, Kottke T. E, Brekke M. L. Will primary care clinics organize themselves to improve the delivery of preventive services? A randomized controlled trial. Prev Med. 98;27(4):623-31. Article focuses on specific preventive measures only.
Solberg L. I, Kottke T. E, Brekke M. L, Conn S. A, Magnan S, Amundson G. The case of the missing clinical preventive services systems. Eff Clin Pract. 98;1(1):33-8. Article focuses on specific preventive measures only.
Solberg L. I, Kottke T. E, Brekke M. L, Magnan S, Davidson G, Calomeni C. A, Conn S. A, Amundson G. M, Nelson A. F. Failure of a continuous quality improvement intervention to increase the delivery of preventive services. A randomized trial. Eff Clin Pract. 2000;3(3):105-15. Exposure not the PHE. [pmid: 11182958].
Solis J. M, Marks G, Garcia M, Shelton D. Acculturation, access to care, and use of preventive services by Hispanics: findings from HHANES 1982-84. Am J Public Health. 90;80(Suppl):11-9. Exposure not the PHE.
SOROKER S. B. Multiphasic screening in a health district of Los Angeles. Public Health Rep. 54;69(8):786-92. Article focuses on specific preventive measures only.
Soucat A, Gandaho T, Levy-Bruhl D, de Bethune X, Alihonou E, Ortiz C, Gbedonou P, Adovohekpe P, Camara O, Ndiaye J. M, Dieng B, Knippenberg R. Health seeking behaviour and household health expenditures in Benin and Guinea: the equity implications of the Bamako Initiative. Int J Health Plann Manage. 97;12(Suppl 1):S137-63. Does not apply to any of the key questions.
SOULE E. H, DAHLIN D. C. Cyto-detection of preclinical carcinoma of cervix; 10 years' experience with initial screening and repeat cervical smears. Mayo Clin Proc. 59;34(1):1-8. Exposure not the PHE.
Spitzer W. O. The periodic health examination: 1. Introduction. Can Med Assoc J. 84;130(10):1276-8. No original data. [pmid: 6722690].
Stange K. C, Fedirko T, Zyzanski S. J, Jaen C. R. How do family physicians prioritize delivery of multiple preventive services?. J Fam Pract. 94;38(3):231-7. Does not apply to any of the key questions.
Stange K. C, Flocke S. A, Goodwin M. A. Opportunistic preventive services delivery. Are time limitations and patient satisfaction barriers?. J Fam Pract. 98;46(5):419-24. Clinical preventive services delivered only durind an opportunistic visit.
Stange K. C, Goodwin M. A, Zyzanski S. J, Dietrich A. J. Sustainability of a practice-individualized preventive service delivery intervention. Am J Prev Med. 2003;25(4):296-300. Exposure not the PHE. [pmid: 14580630].
Stange K. C, Jaen C. R, Flocke S. A, Miller W. L, Crabtree B. F, Zyzanski S. J. The value of a family physician. J Fam Pract. 98;46(5):363-8. No original data. [pmid: 9597993].
Stange K. C, Kelly R. B, Smith C. K, Frank S. Preventive medicine in primary care. Moving from theory to practice. Postgrad Med. 91;90(3):125-8. Does not apply to any of the key questions.
Stave G M, Mignogna J J Powell G S Hunt C M Evaluation of a workplace hemochromatosis screening program (Structured abstract). Exposure not the PHE
Stone E G, Morton S C Hulscher M E Maglione M A Roth E A Grimshaw J M Mittman B S Rubenstein L V Rubenstein L Z Shekelle P G Interventions that increase use of adult immunization and cancer screening services: a meta-analysis (Provisional record). No original data
Stone P W, Teutsch S Chapman R H Bell C Goldie S J Neumann P J Cost-utility analyses of clinical preventive services: published ratios, 1976-1997. Does not apply to any of the key questions
Strickland J, Strickland D. L. Barriers to preventive health services for minority households in the rural south. J Rural Health. 96;12(3):206-17. Exposure not the PHE.
Sudano J. J Jr, Baker D. W. Intermittent lack of health insurance coverage and use of preventive services. Am J Public Health. 2003;93(1):130-7. Exposure not the PHE. [pmid: 12511402]. [pmcid: 1447707].
Sutton M. A, Gibbons R. P, Correa R. J Jr. Is deleting the digital rectal examination a good idea?. West J Med. 91;155(1):43-6. Article focuses on specific preventive measures only.
Svardsudd K, Berglund G, Tibblin G. Morbidity and mortality in untreated and treated hypertension: results from the Goteborg 50-year-old men study. Drugs. 76;11(SUPPL):134-8. Article focuses on specific preventive measures only.
Tabenkin H, Goodwin M. A, Zyzanski S. J, Stange K. C, Medalie J. H. Gender differences in time spent during direct observation of doctor-patient encounters. J Womens Health (Larchmt). 2004;13(3):341-9. Exposure not the PHE. [pmid: 15130263].
Takala J, Kopteff P, Takala A, Sievers K. Use of physician services by a middle-aged population in a rural health centre district in southwest Finland. Descriptive distributions. Scand J Soc Med. 78;6(3):105-9. Exposure not the PHE.
Takala J, Sievers K, Takala A. A multiphasic screening programme at the health centre level: the Sakyla-Koylio project. Scand J Soc Med. 79;7(2):87-91. Does not apply to any of the key questions.
Taylor C. Doctors use multiphasic screening plus personalized patient education. Aust Fam Physician. 79;8(3):296-304. Does not apply to any of the key questions.
Taylor M. P. Periodic health examination combined with multiple screening tests in general practice. J R Coll Gen Pract. 70;19(92):146-57. Does not apply to any of the key questions.
Terris M. Preventive services and medical care: the costs and benefits of basic change. Bull N Y Acad Med. 80;56(1):180-8. Does not apply to any of the key questions.
THAMER, M. A., HARVEY, J. C., and REED, J. W. Development of a multiphasic screening examination for medical care patients--III. Yield of the multiphasic screening examination. J Chronic Dis. 62. 15849–56 Does not apply to any of the key questions
THAMER, M. A., HARVEY, J. C., and REED, J. W. Development of a multiphasic screening examination for medical care patients--II. Sensitivity and specificity of the multiphasic screening examination. J Chronic Dis. 62. 15835–47 Does not apply to any of the key questions Does not apply to any of the key questions
The Danish Medical Research Council, the Danish Hospital Institute Avoidance of deaths from cancer, consensus statement. No original data
Thomas, P., Goetzel, R. Z., Ozminkowski, R. J. Kassabian, V. S. Schutt, D. C. If men won't go to doctors.... Exposure not the PHE
Thompson R. S, Taplin S. H, McAfee T. A, Mandelson M. T, Smith A. E. Primary and secondary prevention services in clinical practice. Twenty years' experience in development, implementation, and evaluation. JAMA. 95;273(14):1130-5. Article focuses on specific preventive measures only.
Thorner R. M. Whither multiphasic screening?. N Engl J Med. 69;280(19):1037-42. No original data. [pmid: 4888177].
Thorner R. M, Djordjevic D, Vuckmanovic C, Pesic B, Culafic B, Mark F. A study to evaluate the effectiveness of multiphasic screening in Yugoslavia. Prev Med. 73;2(2):295-301. Does not apply to any of the key questions.
Tierney WM, Hui SL McDonald CJ Delayed feedback of physician performance versus immediate reminders to perform preventive care. Effects on physician compliance. Exposure not the PHE
Torgerson, B. Breast cancer detection practices in North Dakota's rural long-term care facilities.. Does not apply to any of the key questions
Toth-Pal E, Nilsson G. H, Furhoff A. K. Clinical effect of computer generated physician reminders in health screening in primary health care--a controlled clinical trial of preventive services among the elderly. Int J Med Inform. 2004;73(9-10):695-703. Exposure not the PHE. [pmid: 15325326].
Tudiver, F. and Fuller-Thomson, E. Who has screening mammography? Results from the 1994-1995 National Population Health Survey. Can Fam Physician. 99. 451901–7 Exposure not the PHE
Turner B. J, Day S. C, Borenstein B. A controlled trial to improve delivery of preventive care: physician or patient reminders?. J Gen Intern Med. 89;4(5):403-9. Exposure not the PHE.
Turner, S. M. and Juarez Nurses' exchange: charting preventive services. Pediatr Nurs. 79. 5(4):63–4 Includes only subjects less than 18 years of age
Tyler D. O, Taylor-Seehafer M. A, Murphy-Smith M. Utilizing “PPIP Texas style!” in a medically underserved population. J Public Health Manag Pract. 2004;10(2):100-8. Exposure not the PHE. [pmid: 14967976].
Udvarhelyi I. S, Jennison K, Phillips R. S, Epstein A. M. Comparison of the quality of ambulatory care for fee-for-service and prepaid patients. Ann Intern Med. 91;115(5):394-400. Exposure not the PHE.
Urbanoski K. A. The use of preventive healthcare by Canadian women who drink alcohol. Prev Med. 2003;37(4):334-41. Exposure not the PHE. [pmid: 14507490].
van Walraven C, Goel V, Austin P. Why are investigations not recommended by practice guidelines ordered at the periodic health examination?. J Eval Clin Pract. 2000;6(2):215-24. No eligible comparison group. [pmid: 10970015].
Velitzelou, K. Preventive health screening in Greece.. No original data
Vincent, E. C., Hardin, P. A., Norman, L. A., Lester, E. A., and Stinton, S. H. The effects of a computer-assisted reminder system on patient compliance with recommended health maintenance procedures. Proc Annu Symp Comput Appl Med Care. 95. 656–60 Exposure not the PHE
Vinokur Amiram D, Price Richard H Caplan Robert D van Ryn Michelle Curran Joan The Jobs 1 Preventive Intervention for Unemployed Individuals: Short- and Long-Term Effects on Reemployment and Mental Health. Does not apply to any of the key questions
Vogt T M Cost-effectiveness of prevention programs for older people. No original data
WADE, L., THORPE, J., ELIAS, T., and BOCK, G. Are periodic health examinations worth-while?. Ann Intern Med. 62. 5681–93 No eligible comparison group
Wagner EH, Grothaus LC Sandhu N Galvin MS McGregor M Artz K Coleman EA Chronic care clinics for diabetes in primary care: a system-wide randomized trial.. Exposure not the PHE
Walker, S. Role of the nurse in the multiphasic screening program. Trans Natl Saf Congr. 71. 1820 Does not apply to any of the key questions
Walker, S. Role of the nurse in the multiphasic screening program. Trans Natl Saf Congr. 70. 1820 Does not apply to any of the key questions
Walker S, Kubitz M. C. Midland, Michigan--U.S.A. Periodic physical examinations. Occup Health Nurs. 69;17(6):16-7. Does not apply to any of the key questions.
Wall M, Teeland L. Non-participants in a preventive health examination for cardiovascular disease: characteristics, reasons for non-participation, and willingness to participate in the future. Scand J Prim Health Care. 2004;22(4):248-51. Exposure not the PHE. [pmid: 15765642].
Wallinder, J. Population-based nursing. New guide for community preventive services available.. No original data
Wang T. G, Chen Y. D, Yang H, Peng R. C. Changes in the health situation among the rural population and the challenges to the preventive services in China. Asia Pac J Public Health. 87;1(2):39-43. No original data.
Wang Y. R, Pauly M. V. Difference in the use of preventive services between fee-for-service plans and HMOs: is more better?. Am J Manag Care. 2003;9(4):293-301. Exposure not the PHE. [pmid: 12703673].
Wang Y. R, Pauly M. V. Preventive care in managed care and fee-for-service plans: is it cost effective?. Manag Care Interface. 2003;16(2):47-50. No original data.
Way D, Jones L, Baskerville B, Busing N. Primary health care services provided by nurse practitioners and family physicians in shared practice. CMAJ. 2001;165(9):1210-4. Exposure not the PHE. [pmid: 11706910]. [pmcid: 81583].
Weber T. B. Multiphasic screening--the next generation. Occup Health Nurs. 69;17(7):22-6. Does not apply to any of the key questions. [pmid: 5815361].
Weber T. B. Multiphasic screening: the next generation. J Occup Med. 69;11(7):369-73. Does not apply to any of the key questions. [pmid: 5804926].
Weeks J. L, Peters J. M, Monson R. R. Screening for occupational health hazards in the rubber industry. Part II: health hazards in the curing department. Am J Ind Med. 81;2(2):143-51. Exposure not the PHE.
Weeks J. L, Peters J. M, Monson R. R. Screening for occupational health hazards in the rubber industry. Part I. Am J Ind Med. 81;2(2):125-41. Exposure not the PHE.
Weigley E. S, Kornblueh M. Implications for nutritional programs in multiphasic screening. J Am Diet Assoc. 67;50(1):42. Exposure not the PHE. [pmid: 6020072].
WEINERMAN E. R, BRESLOW L, BELLOC N. B, WAYBUR A, MILMORE B. K. Multiphasic screening of longshoremen with organized medical follow-up. Am J Public Health. 52;42(12):1552-67. Exposure not the PHE.
Weinick R. M, Beauregard K. M. Women's use of preventive screening services: a comparison of HMO versus fee-for-service enrollees. Med Care Res Rev. 97;54(2):176-99. Article focuses on specific preventive measures only.
Weisman, C. S., Cassard, S. D., Plichta, S. B. Types of physicians used by women for regular health care: implications for services received.. Exposure not the PHE
Weiss L J, Blustein J Faithful patients: the effect of long-term physician-patient relationships on the costs and use of health care by older Americans. Exposure not the PHE
Werner M, Altshuler C. H. Cost effectiveness of multiphasic screening: old controversies and a new rationale. Hum Pathol. 81;12(2):111-7. Exposure not the PHE.
Weyer S. M, Konrad N, Esola D, Goodwin M. A, Stange K. C, Flocke S. A. Features of medical records in community practices and their association with preventive service delivery. Med Care. 2005;43(1):28-33. Exposure not the PHE. [pmid: 15626931].
WILBAR, C. L. Jr Periodic physical examination of drivers. Public Health Rep. 62. 77577–82 Exposure not the PHE
Wilkinson D, Gouws E, Sach M, Karim S. S. Effect of removing user fees on attendance for curative and preventive primary health care services in rural South Africa. Bull World Health Organ. 2001;79(7):665-71. Exposure not the PHE. [pmid: 11477970].
Will JC, Massoudi B Mokdad A Ford ES Rosamond W Stoddard AM Palombo SR Holliday J Byers T Ammerman A Troped P Sorensen G Reducing risk for cardiovascular disease in uninsured women: combined results from two WISEWOMAN projects.. Exposure not the PHEM
Williams SJ, Elder JP Seidman RL Mayer JA Preventive services in a Medicare managed care environment.. Exposure not the PHE
Williams G. The periodic health examination: is it obsolete?. Del Med J. 77;49(1):31-4. No original data. [pmid: 401747].
Williams P. A. A productive history and physical examination in the prevention and early detection of cancer. Cancer. 81;47(5 Suppl):1146-50. Does not apply to any of the key questions.
Williams R. L, Flocke S. A, Stange K. C. Race and preventive services delivery among black patients and white patients seen in primary care. Med Care. 2001;39(11):1260-7. Exposure not the PHE. [pmid: 11606879].
Williams S. J, Elder J. P, Seidman R. L, Mayer J. A. Preventive services in a Medicare managed care environment. J Community Health. 97;22(6):417-34. Exposure not the PHE.
Williamson P. S, Driscoll C. E, Dvorak L. D, Garber K. A, Shank J. C. Health screening examinations: the patient's perspective. J Fam Pract. 88;27(2):187-92. Does not apply to any of the key questions.
Wilner D. M. Mobile multiphasic screening in an industrial setting. J Occup Med. 69;11(11):590. Exposure not the PHE. [pmid: 5348638].
Winters, K. C. Screening and assessing adolescents for substance use disorders.. Exposure not the PHE
Woloshin S, Schwartz L. M, Katz S. J, Welch H. G. Is language a barrier to the use of preventive services?. J Gen Intern Med. 97;12(8):472-7. Exposure not the PHE.
Won J. U, Song J. S, Ahn Y. S, Roh J. H, Park C. Y. Analysis of factors associated with the workers' health status using periodic health examination data by size of enterprises. Yonsei Med J. 2002;43(1):14-9. Exposure not the PHE. [pmid: 11854926].
Wong M D, Hollenberg J P Charlson M E A comparison of clinical performance of primary care and traditional internal medicine residents (Structured abstract). Exposure not the PHE
Woolf S. H. The periodic health examination. J Am Coll Health. 90;38(6):299. No original data. [pmid: 2355150].
Woolf S. H. Preventive services closely linked to quality concerns. QA Rev. 90;2(4):6. Does not apply to any of the key questions. [pmid: 10113751].
Wreford B. M. A health check clinic: multiphasic screening at the Cavendish Bio-medical Centre. Occup Health (Lond). 70;22(8):247-54. Exposure not the PHE.
Wright P. J, Fortinsky R. H, Covinsky K. E, Anderson P. A, Landefeld C. S. Delivery of preventive services to older black patients using neighborhood health centers. J Am Geriatr Soc. 2000;48(2):124-30. Exposure not the PHE. [pmid: 10682940].
Wynder E. L. Preventive medicine welcomes a status report on multiphasic health testing. Prev Med. 73;2(2):iv. Exposure not the PHE. [pmid: 4723643].
Xu K. T. Usual source of care in preventive service use: a regular doctor versus a regular site. Health Serv Res. 2002;37(6):1509-29. Exposure not the PHE. [pmid: 12546284]. [pmcid: 1464041].
Xu, X. and Jensen, G. A. Utilization of health care services among the near-elderly: a comparison of managed care and fee-for-service enrollees. Manag Care Interface. 2005. 18(3):60–6, 70 Exposure not the PHE
Yeazel M. W, Bunner S. H, Kofron P. M, Weiss P. J. Put prevention into practice (PPIP): evaluating PPIP in two family practice residency sites. Fam Med. 2002;34(1):17-22. Exposure not the PHE. [pmid: 11838522].
Yi J. K. Acculturation, access to care and use preventive health services by Vietnamese women. Asian Am Pac Isl J Health. 95;3(1):30-41. Exposure not the PHE.
Zyzanski S. J, Stange K. C, Langa D, Flocke S. A. Trade-offs in high-volume primary care practice. J Fam Pract. 98;46(5):397-402. Article focuses on specific.