# Appendix C: Exact Search Strategies

## MEDLINE Strategy

(“Periodic physical examination”[tiab] OR “Periodic physical examinations”[tiab] OR “Periodic health examination”[tiab] OR “Periodic health examinations”[tiab] OR “Periodic health evaluations”[tiab] OR “Periodic screening”[tiab] OR “Periodic check up”[tiab] OR “Periodic checkup”[tiab] OR “Annual physical examination”[tiab] OR “Annual physical examinations”[tiab] OR “Annual health examination”[tiab] OR “Annual health examinations”[tiab] OR “Annual screen”[tiab] OR “Annual screening”[tiab] OR “Annual health check up”[tiab] OR “Annual check up”[tiab] OR “Annual checkup”[tiab] OR “Multiphasic health examination”[tiab] OR “Multiphasic screening”[tiab] OR “Multiphasic checkup”[tiab] OR “Multiphasic Health testing “[tiab] OR “Preventive health examinations”[tiab] OR “Preventive screening”[tiab] OR “primary care screening”[tiab] OR “Initial physical examination”[tiab] OR “Initial screen”[tiab] OR “Initial screening”[tiab] OR “Initial check up”[tiab] OR “preventive services delivery”[tiab] OR “preventive service delivery”[tiab] OR “preventive service”[tiab] OR “preventive services”[tiab] OR “well care visit”[tiab] OR “well care visits” [tiab]) NOT (animal[mh] NOT human[mh]) AND English[lang] | 4827

## Cochrane Library (all databases)

( Periodic NEAR (examination OR physical OR health OR evaluation OR screening OR checkup)) OR (Multiphasic NEAR (health OR examination OR screen OR screening OR checkup OR testing)) OR ( Preventive NEAR (health OR examination OR screening OR screen OR services OR delivery)) | 782

## CINAHL Strategy

((TX Periodic W1 Health W1 Examination) OR ( TX Periodic W1 Health W1 Evaluation)) OR (( TX Annual W1 physical) OR (TX Annual W1 health W1 examination) OR ( TX Annual W1 checkup)) OR ((TX Multiphasic W1 Health W1 screening) OR ( TX Multiphasic W1 Health W1 testing)) OR (( TX Preventive W1 Health W1 Examination) OR ( TX Preventive W1 Health W1 screening) OR ( TX Preventive W1 Health W1 services) OR ( TX Preventive W1 screening) OR ( TX Preventive W1 services)) OR (( TX Initial W1 screening) OR ( TX Initial W1 screen)) | 1207