# Appendix B: Hand Searched Journals

## All Journals Hand Searched January 2005 through January 2006

American Family Physician

American Journal of Managed Care

American Journal of Preventive Medicine

American Journal of Public Health

Annals of Internal Medicine

Archives of Family Medicine

Archives of Internal Medicine

Canadian Family Physician

Canadian Medical Association Journal

Cancer

Family Medicine

Journal of Community Health

Journal of Family Practice

Journal of General Internal Medicine

Journal of Occupational Medicine

Journal of the American Academy of Nurse Practitioners

Journal of the American Geriatrics Society

Journal of the American Medical Association (JAMA)

Mayo Clinic Proceedings

Medical Care

Medical Journal of Australia

New England Journal of Medicine

Preventive Medicine

Public Health Reports