# Appendix A: Technical Experts and Peer Reviewers

- Harold Sox, MD, MACP
- Editor-in-Chief, Annals of Internal Medicine
- 190 N. Independence Mall West
- Philadelphia, PA 19106

- J. Sanford Schwartz, MD
- University of Pennsylvania
- School of Medicine
- Philadelphia, PA

- Karen DeSalvo, MD, MPH
- Chief, Section of General Internal Medicine
- Office of Health Research
- Tulane University
- School of Medicine
- New Orleans, LA

- Russell Harris, MD, MPH
- Sheps Center for Health Services Research
- University of North Carolina
- School of Medicine
- Chapel Hill, NC

- J. Thomas Cross, Jr., MD, MPH
- Vice President, Education
- MedStudy Corporation
- Colorado Springs, CO

- Nancy Keating, MD, MPH
- Department of Health Care Policy
- Harvard Medical School
- Boston, MA

- Robert Smith, PhD
- Director of Cancer Screening
- American Cancer Society

- Paul S. Frame, MD
- Tri-County Family Medicine
- Cohocton, NY

- Subash Babu Duggirala, MD, MPH, FAAFP
- Senior Medical Officer
- CMS
- Baltimore, MD

- Vincenza Snow, MD
- American College of Physicians
- Philidelphia, PA

- Wayne N. Burton, MD
- Senior Vice President,Medical Executive
- JPMorgan Chase
- Chicago, IL

- Mike LeFevre, MD
- University of Missouri-Columbia
- Columbia, MO

- Alfred Berg, MD, MPH
- Professor and Chair
- Department of Family Medicine
- University of Washington
- Seattle, WA

- Bob Rehm, MBA
- Director, Public Health Strategies
- America's Health Insurance Plans
- Washington, DC

## Internal Technical Experts

- Wanda Nicholson, MD, MPH
- The Johns Hopkins Hospital
- Gynecology-Obstetrics
- Baltimore, MD

- Daniel Ford, MD, MPH
- Professor
- Division of General Internal Medicine
- Johns Hopkins University
- School of Medicine
- Baltimore, MD

- Robert Lawrence, MD
- Associate Dean
- Bloomberg School of Public Health
- Professional Education Programs
- Johns Hopkins University
- Baltimore, MD