# Appendixes

Appendix A: Technical Experts and Peer Reviewers

Appendix B: Hand Searched Journals

Appendix C: Exact Search Strategies

Appendix D: Example Review Forms

Appendix E: Listing of Included and Excluded Articles

Appendix F: Study Nomenclature

Appendix G: Evidence Tables