# References for Evidence Tables

Agras WS, Rossiter EM, Arnow B, et al. Pharmacologic and cognitive-behavioral treatment for bulimia nervosa: a controlled comparison. Am J Psychiatry. 1992;149(1):82-7. [pmid: 1728190].
Agras WS, Rossiter EM, Arnow B, et al. One-year follow-up of psychosocial and pharmacologic treatments for bulimia nervosa. J Clin Psychiatry. 1994;55(5):179-83. [pmid: 8071266].
Agras WS, Schneider JA, Arnow B, et al. Cognitive-behavioral and response-prevention treatments for bulimia nervosa. J Consult Clin Psychol. 1989;57(2):215-21. [pmid: 2708607].
Agras WS, Telch CF, Arnow B, et al. Does interpersonal therapy help patients with binge eating disorder who fail to respond to cognitive-behavioral therapy. J Consult Clin Psychol. 1995;63(3):356-60. [pmid: 7608347].
Agras WS, Telch CF, Arnow B, et al. Weight loss, cognitive-behavioral, and desipramine treatments in binge eating disorder: an additive design. Behavior Therapy. 1994;25:225-38.
Agras WS, Walsh T, Fairburn CG, et al. A multicenter comparison of cognitive-behavioral therapy and interpersonal psychotherapy for bulimia nervosa. Arch Gen Psychiatry. 2000;57(5):459-66. [pmid: 10807486].
Appolinario JC, Bacaltchuk J, Sichieri R, et al. A randomized, double-blind, placebo-controlled study of sibutramine in the treatment of binge-eating disorder. Arch Gen Psychiatry. 2003;60(11):1109-16. [pmid: 14609886].
Arnold LM, McElroy SL, Hudson JI, et al. A placebo-controlled, randomized trial of fluoxetine in the treatment of binge-eating disorder. J Clin Psychiatry. 2002;63(11):1028-33. [pmid: 12444817].
Attia E, Haiman C, Walsh BT, et al. Does fluoxetine augment the inpatient treatment of anorexia nervosa. Am J Psychiatry. 1998;155(4):548-51. [pmid: 9546003].
Bailer U, de Zwaan M, Leisch F, et al. Guided self-help versus cognitive-behavioral group therapy in the treatment of bulimia nervosa. Int J Eat Disord. 2004;35(4):522-37. [pmid: 15101068].
Barbarich NC, McConaha CW, Halmi KA, et al. Use of nutritional supplements to increase the efficacy of fluoxetine in the treatment of anorexia nervosa. Int J Eat Disord. 2004;35(1):10-5. [pmid: 14705152].
Ben-Tovim DI, Walker K, Gilchrist P, et al. Outcome in patients with eating disorders: a 5-year study. Lancet. 2001;357(9264):1254-7. [pmid: 11418150].
Beumont PJ, Russell JD, Touyz SW, et al. Intensive nutritional counselling in bulimia nervosa: a role for supplementation with fluoxetine?. Aust N Z J Psychiatry. 1997;31(4):514-24. [pmid: 9272261].
Biederman J, Herzog DB, Rivinus TM, et al. Amitriptyline in the treatment of anorexia nervosa: a double-blind, placebo-controlled study. J Clin Psychopharmacol. 1985;5(1):10-6. [pmid: 3973067].
Birmingham CL, Goldner EM, Bakan R. Controlled trial of zinc supplementation in anorexia nervosa. Int J Eat Disord. 1994;15(3):251-5. [pmid: 8199605].
Birmingham CL, Gutierrez E, Jonat L, et al. Randomized controlled trial of warming in anorexia nervosa. Int J Eat Disord. 2004;35(2):234-8. [pmid: 14994363].
Birmingham C, Su J, Hlynsky J, et al. The mortality rate from anorexia nervosa. Int J Eat Disord. 2005;38:143-6. [pmid: 16134111].
Brambilla F, Draisci A, Peirone A, et al. Combined cognitive-behavioral, psychopharmacological and nutritional therapy in eating disorders. 2. Anorexia nervosa--binge-eating/purging type. Neuropsychobiology. 1995;32(2):64-7. [pmid: 7477801].
Braun DL, Sunday SR, Fornari VM, et al. Bright light therapy decreases winter binge frequency in women with bulimia nervosa: a double-blind, placebo-controlled study. Compr Psychiatry. 1999;40(6):442-8. [pmid: 10579376].
Bulik CM, Sullivan PF, Carter FA, et al. The role of exposure with response prevention in the cognitive-behavioural therapy for bulimia nervosa. Psychol Med. 1998;28(3):611-23. [pmid: 9626717].
Bulik CM, Sullivan PF, Fear JL, et al. Outcome of anorexia nervosa: eating attitudes, personality, and parental bonding. Int J Eat Disord. 2000;28(2):139-47. [pmid: 10897075].
Bulik CM, Sullivan PF, Joyce PR, et al. Predictors of 1-year treatment outcome in bulimia nervosa. Compr Psychiatry. 1998;39(4):206-14. [pmid: 9675505].
Busetto L, Segato G, De Luca M, et al. Weight loss and postoperative complications in morbidly obese patients with binge eating disorder treated by laparoscopic adjustable gastric banding. Obes Surg. 2005;15(2):195-201. [pmid: 15802061].
Carruba MO, Cuzzolaro M, Riva L, et al. Efficacy and tolerability of moclobemide in bulimia nervosa: a placebo-controlled trial. Int Clin Psychopharmacol. 2001;16(1):27-32. [pmid: 11195257].
Carter FA, McIntosh VV, Joyce PR, et al. Role of exposure with response prevention in cognitive-behavioral therapy for bulimia nervosa: three-year follow-up results. Int J Eat Disord. 2003;33(2):127-35. [pmid: 12616578].
Carter JC, Fairburn CG. Cognitive-behavioral self-help for binge eating disorder: a controlled effectiveness study. J Consult Clin Psychol. 1998;66(4):616-23. [pmid: 9735577].
Carter JC, Olmsted MP, Kaplan AS, et al. Self-help for bulimia nervosa: a randomized controlled trial. Am J Psychiatry. 2003;160(5):973-8. [pmid: 12727703].
Channon S, de Silva P, Hemsley D, et al. A controlled trial of cognitive-behavioural and behavioural treatment of anorexia nervosa. Behav Res Ther. 1989;27(5):529-35. [pmid: 2684134].
Chen E, Touyz SW, Beumont PJ, et al. Comparison of group and individual cognitive-behavioral therapy for patients with bulimia nervosa. Int J Eat Disord. 2003;33(3):241-54. discussion 255-6. [pmid: 12655619].
Cooper PJ, Steere J. A comparison of two psychological treatments for bulimia nervosa: implications for models of maintenance. Behav Res Ther. 1995;33(8):875-85. [pmid: 7487847].
Crisp AH, Callender JS, Halek C, et al. Long-term mortality in anorexia nervosa. A 20-year follow-up of the St George's and Aberdeen cohorts. Br J Psychiatry. 1992;161:104-7. [pmid: 1638303].
Crisp AH, Norton K, Gowers S, et al. A controlled study of the effect of therapies aimed at adolescent and family psychopathology in anorexia nervosa. Br J Psychiatry. 1991;159:325-33. [pmid: 1958942].
Crosby RD, Mitchell JE, Raymond N, et al. Survival analysis of response to group psychotherapy in bulimia nervosa. Int J Eat Disord. 1993;13(4):359-68. [pmid: 8490638].
Dancyger IF, Sunday SR, Eckert ED, et al. A comparative analysis of Minnesota Multiphasic Personality Inventory profiles of anorexia nervosa at hospital admission, discharge, and 10-year follow-up. Compr Psychiatry. 1997;38(3):185-91. [pmid: 9154376].
Dare C, Eisler I, Russell G, et al. Psychological therapies for adults with anorexia nervosa: randomised controlled trial of out-patient treatments. Br J Psychiatry. 2001;178:216-21. [pmid: 11230031].
Davis R, McVey G, Heinmaa M, et al. Sequencing of cognitive-behavioral treatments for bulimia nervosa. Int J Eat Disord. 1999;25(4):361-74. [pmid: 10202647].
Deter HC, Herzog W. Anorexia nervosa in a long-term perspective: results of the Heidelberg-Mannheim Study. Psychosom Med. 1994;56(1):20-7. [pmid: 8197311].
Deter HC, Schellberg D, Kopp W, et al. Predictability of a favorable outcome in anorexia nervosa. Eur Psychiatry. 2005;20(2):165-72. [pmid: 15797702].
Durand MA, King M. Specialist treatment versus self-help for bulimia nervosa: a randomised controlled trial in general practice. Br J Gen Pract. 2003;53(490):371-7. [pmid: 12830564]. [pmcid: 1314596].
Eckert ED, Halmi KA, Marchi P, et al. Ten-year follow-up of anorexia nervosa: clinical course and outcome. Psychol Med. 1995;25(1):143-56. [pmid: 7792349].
Eddy K, Keel P, Dorer D, et al. Longitudinal comparison of anorexia nervosa subtypes. Int J Eat Disord. 2002;31(2):191-201. [pmid: 11920980].
Eisler I, Dare C, Hodes M, et al. Family therapy for adolescent anorexia nervosa: the results of a controlled comparison of two family interventions. J Child Psychol Psychiatry. 2000;41(6):727-36. [pmid: 11039685].
Eisler I, Dare C, Russell G, et al. Family and individual therapy in anorexia nervosa. A 5-year follow-up. Arch Gen Psychiatry. 1997;54(11):1025-30. [pmid: 9366659].
Eldredge KL, Stewart Agras W, Arnow B, et al. The effects of extending cognitive-behavioral therapy for binge eating disorder among initial treatment nonresponders. Int J Eat Disord. 1997;21(4):347-52. [pmid: 9138046].
Esplen MJ, Garfinkel PE, Olmsted M, et al. A randomized controlled trial of guided imagery in bulimia nervosa. Psychol Med. 1998;28(6):1347-57. [pmid: 9854276].
Fairburn CG, Cooper Z, Doll HA, et al. The natural course of bulimia nervosa and binge eating disorder in young women. Arch Gen Psychiatry. 2000;57(7):659-65. [pmid: 10891036].
Fairburn CG, Jones R, Peveler RC, et al. Three psychological treatments for bulimia nervosa. A comparative trial. Arch Gen Psychiatry. 1991;48(5):463-9. [pmid: 2021299].
Fairburn CG, Jones R, Peveler RC, et al. Psychotherapy and bulimia nervosa. Longer-term effects of interpersonal psychotherapy, behavior therapy, and cognitive behavior therapy. Arch Gen Psychiatry. 1993;50(6):419-28. [pmid: 8498876].
Fairburn CG, Norman PA, Welch SL, et al. A prospective study of outcome in bulimia nervosa and the long-term effects of three psychological treatments. Arch Gen Psychiatry. 1995;52(4):304-12. [pmid: 7702447].
Fairburn CG, Peveler RC, Jones R, et al. Predictors of 12-month outcome in bulimia nervosa and the influence of attitudes to shape and weight. J Consult Clin Psychol. 1993;61(4):696-8. [pmid: 8370866].
Fairburn CG, Stice E, Cooper Z, et al. Understanding persistence in bulimia nervosa: a 5-year naturalistic study. J Consult Clin Psychol. 2003;71(1):103-9. [pmid: 12602430].
Faris PL, Kim SW, Meller WH, et al. Effect of decreasing afferent vagal activity with ondansetron on symptoms of bulimia nervosa: a randomised, double-blind trial. Lancet. 2000;355(9206):792-7. [pmid: 10711927].
Fassino S, Leombruni P, Daga G, et al. Efficacy of citalopram in anorexia nervosa: a pilot study. Eur Neuropsychopharmacol. 2002;12(5):453-9. [pmid: 12208563].
Fichter MM, Kruger R, Rief W, et al. Fluvoxamine in prevention of relapse in bulimia nervosa: effects on eating-specific psychopathology. J Clin Psychopharmacol. 1996;16(1):9-18. [pmid: 8834413].
Fichter MM, Leibl C, Kruger R, et al. Effects of fluvoxamine on depression, anxiety, and other areas of general psychopathology in bulimia nervosa. Pharmacopsychiatry. 1997;30(3):85-92. [pmid: 9211569].
Fichter MM, Leibl K, Rief W, et al. Fluoxetine versus placebo: a double-blind study with bulimic inpatients undergoing intensive psychotherapy. Pharmacopsychiatry. 1991;24(1):1-7. [pmid: 2011615].
Fichter MM, Quadflieg N. Six-year course and outcome of anorexia nervosa. Int J Eat Disord. 1999;26(4):359-85. [pmid: 10550777].
Fichter MM, Quadflieg N. Six-year course of bulimia nervosa. Int J Eat Disord. 1997;22(4):361-84. [pmid: 9356885].
Fichter MM, Quadflieg N. Twelve-year course and outcome of bulimia nervosa. Psychol Med. 2004;34(8):1395-406. [pmid: 15724871].
Fichter MM, Quadflieg N, Gnutzmann A. Binge eating disorder: treatment outcome over a 6-year course. J Psychosom Res. 1998;44(34):385-405. [pmid: 9587882].
Fluoxetine Bulimia Nervosa Collaborative Study Group. Fluoxetine in the treatment of bulimia nervosa. A multicenter, placebo-controlled, double-blind trial. Fluoxetine Bulimia Nervosa Collaborative Study Group. Arch Gen Psychiatry. 1992;49(2):139-47. [pmid: 1550466].
Franko DL, Keel PK, Dorer DJ, et al. What predicts suicide attempts in women with eating disorders. Psychol Med. 2004;34(5):843-53. [pmid: 15500305].
Garner DM, Rockert W, Davis R, et al. Comparison of cognitive-behavioral and supportive-expressive therapy for bulimia nervosa. Am J Psychiatry. 1993;150(1):37-46. [pmid: 8417578].
Geist R, Heinmaa M, Stephens D, et al. Comparison of family therapy and family group psychoeducation in adolescents with anorexia nervosa. Can J Psychiatry. 2000;45(2):173-8. [pmid: 10742877].
Gendall KA, Bulik CM, Joyce PR, et al. Menstrual cycle irregularity in bulimia nervosa. Associated factors and changes with treatment. J Psychosom Res. 2000;49(6):409-15. [pmid: 11182433].
Gillberg C, Råstam M, Gillberg IC. Anorexia nervosa: physical health and neurodevelopment at 16 and 21 years. Dev Med Child Neurol. 1994;36(7):567-75. [pmid: 8034118].
Gillberg IC, Råstam M, Gillberg C. Anorexia nervosa 6 years after onset: Part I, Personality disorders. Compr Psychiatry. 1995;36(1):61-9. [pmid: 7705090].
Gillberg IC, Råstam M, Gillberg C. Anorexia nervosa outcome: six-year controlled longitudinal study of 51 cases including a population cohort. J Am Acad Child Adolesc Psychiatry. 1994;33(5):729-39. [pmid: 8056736].
Goldbloom DS, Olmsted M, Davis R, et al. A randomized controlled trial of fluoxetine and cognitive behavioral therapy for bulimia nervosa: short-term outcome. Behav Res Ther. 1997;35(9):803-11. [pmid: 9299800].
Goldstein DJ, Wilson MG, Ascroft RC, et al. Effectiveness of fluoxetine therapy in bulimia nervosa regardless of comorbid depression. Int J Eat Disord. 1999;25(1):19-27. [pmid: 9924649].
Goldstein DJ, Wilson MG, Thompson VL, et al. Long-term fluoxetine treatment of bulimia nervosa. Fluoxetine Bulimia Nervosa Research Group. Br J Psychiatry. 1995;166(5):660-6. [pmid: 7620754].
Gorin A, Le Grange D, Stone A. Effectiveness of spouse involvement in cognitive behavioral therapy for binge eating disorder. Int J Eat Disord. 2003;33(4):421-33. [pmid: 12658672].
Gowers S, Norton K, Halek C, et al. Outcome of outpatient psychotherapy in a random allocation treatment study of anorexia nervosa. Int J Eat Disord. 1994;15(2):165-77. [pmid: 8173562].
Gowers SG, Weetman J, Shore A, et al. Impact of hospitalisation on the outcome of adolescent anorexia nervosa. Br J Psychiatry. 2000;176:138-41. [pmid: 10755050].
Griffiths RA, Hadzi-Pavlovic D, Channon-Little L. A controlled evaluation of hypnobehavioural treatment for bulimia nervosa: immediate pre-post treatment effects. Eur Eat Disord Rev. 1994;2(4):202-20.
Grilo CM, Masheb RM, Salant SL. Cognitive behavioral therapy guided self-help and orlistat for the treatment of binge eating disorder: a randomized, double-blind, placebo-controlled trial. Biol Psychiatry. 2005;57(10):1193-201. [pmid: 15866560].
Grilo CM, Masheb RM, Wilson GT. Efficacy of cognitive behavioral therapy and fluoxetine for the treatment of binge eating disorder: a randomized double-blind placebo-controlled comparison. Biol Psychiatry. 2005;57(3):301-9. [pmid: 15691532].
Hall A, Crisp AH. Brief psychotherapy in the treatment of anorexia nervosa. Outcome at one year. Br J Psychiatry. 1987;151:185-91. [pmid: 3690108].
Halmi K, Eckert E, Marchi P, et al. Comorbidity of psychiatric diagnoses in anorexia nervosa. Arch Gen Psychiatry. 1991;48:712-8. [pmid: 1883254].
Halmi KA, Eckert E, LaDu TJ, et al. Anorexia nervosa. Treatment efficacy of cyproheptadine and amitriptyline. Arch Gen Psychiatry. 1986;43(2):177-81. [pmid: 3511877].
Halvorsen I, Andersen A, Heyerdahl S. Good outcome of adolescent onset anorexia nervosa after systematic treatment. Intermediate to long-term follow-up of a representative county-sample. Eur Child Adolesc Psychiatry. 2004;13(5):295-306. [pmid: 15490277].
Hebebrand J, Himmelmann GW, Herzog W, et al. Prediction of low body weight at long-term follow-up in acute anorexia nervosa by low body weight at referral. Am J Psychiatry. 1997;154(4):566-9. [pmid: 9090350].
Hedges DW, Reimherr FW, Hoopes SP, et al. Treatment of bulimia nervosa with topiramate in a randomized, double-blind, placebo-controlled trial, part 2: improvement in psychiatric measures. J Clin Psychiatry. 2003;64(12):1449-54. [pmid: 14728106].
Herzog DB, Dorer DJ, Keel PK, et al. Recovery and relapse in anorexia and bulimia nervosa: a 7.5-year follow-up study. J Am Acad Child Adolesc Psychiatry. 1999;38(7):829-37. [pmid: 10405500].
Herzog DB, Field AE, Keller MB, et al. Subtyping eating disorders: is it justified. J Am Acad Child Adolesc Psychiatry. 1996;35(7):928-36. [pmid: 8768354].
Herzog DB, Greenwood DN, Dorer DJ, et al. Mortality in eating disorders: a descriptive study. Int J Eat Disord. 2000;28(1):20-6. [pmid: 10800010].
Herzog DB, Sacks NR, Keller MB, et al. Patterns and predictors of recovery in anorexia nervosa and bulimia nervosa. J Am Acad Child Adolesc Psychiatry. 1993;32(4):835-42. [pmid: 8340307].
Herzog W, Deter HC, Fiehn W, et al. Medical findings and predictors of long-term physical outcome in anorexia nervosa: a prospective, 12-year follow-up study. Psychol Med. 1997;27(2):269-79. [pmid: 9089820].
Herzog W, Schellberg D, Deter HC. First recovery in anorexia nervosa patients in the long-term course: a discrete-time survival analysis. J Consult Clin Psychol. 1997;65(1):169-77. [pmid: 9103746].
Hilbert A, Tuschen-Caffier B. Body image interventions in cognitive-behavioural therapy of binge-eating disorder: a component analysis. Behav Res Ther. 2004;42(11):1325-39. [pmid: 15381441].
Hill K, Bucuvalas J, McClain C, et al. Pilot study of growth hormone administration during the refeeding of malnourished anorexia nervosa patients. J Child Adolesc Psychopharmacol. 2000;10(1):3-8. [pmid: 10755576].
Hoopes SP, Reimherr FW, Hedges DW, et al. Treatment of bulimia nervosa with topiramate in a randomized, double-blind, placebo-controlled trial, part 1: improvement in binge and purge measures. J Clin Psychiatry. 2003;64(11):1335-41. [pmid: 14658948].
Hsu LK, Rand W, Sullivan S, et al. Cognitive therapy, nutritional therapy and their combination in the treatment of bulimia nervosa. Psychol Med. 2001;31(5):871-9. [pmid: 11459384].
Hudson JI, McElroy SL, Raymond NC, et al. Fluvoxamine in the treatment of binge-eating disorder: a multicenter placebo-controlled, double-blind trial. Am J Psychiatry. 1998;155(12):1756-62. [pmid: 9842788].
Isager T, Brinch M, Kreiner S, et al. Death and relapse in anorexia nervosa: survival analysis of 151 cases. J Psychiatr Res. 1985;19(23):515-21. [pmid: 4045762].
Ivarsson T, Råstam M, Wentz E, et al. Depressive disorders in teenage-onset anorexia nervosa: a controlled longitudinal, partly community-based study. Compr Psychiatry. 2000;41(5):398-403. [pmid: 11011838].
Johnson C, Tobin DL, Dennis A. Differences in treatment outcome between borderline and nonborderline bulimics at one-year follow-up. Int J Eat Dis. 1990;9(6):617-27.
Jäger B, Liedtke R, Lamprecht F, et al. Social and health adjustment of bulimic women 7–9 years following therapy. Acta Psychiatr Scand. 2004;110(2):138-45. [pmid: 15233714].
Kanerva R, Rissanen A, Sarna S. Fluoxetine in the treatment of anxiety, depressive symptoms, and eating-related symptoms in bulimia nervosa. Nord J Psychiatry. 1994;49(7):237-42.
Kaye WH, Nagata T, Weltzin TE, et al. Double-blind placebo-controlled administration of fluoxetine in restricting- and restricting-purging-type anorexia nervosa. Biol Psychiatry. 2001;49(7):644-52. [pmid: 11297722].
Keel PK, Mitchell JE, Davis TL, et al. Relationship between depression and body dissatisfaction in women diagnosed with bulimia nervosa. Int J Eat Disord. 2001;30(1):48-56. [pmid: 11439408].
Keel PK, Mitchell JE, Davis TL, et al. Impact of definitions on the description and prediction of bulimia nervosa outcome. Int J Eat Disord. 2000;28(4):377-86. [pmid: 11054784].
Keel PK, Mitchell JE, Miller KB, et al. Long-term outcome of bulimia nervosa. Arch Gen Psychiatry. 1999;56(1):63-9. [pmid: 9892257].
Keel PK, Mitchell JE, Miller KB, et al. Predictive validity of bulimia nervosa as a diagnostic category. Am J Psychiatry. 2000;157(1):136-8. [pmid: 10618030].
Keel PK, Dorer DJ, Eddy KT, et al. Predictors of mortality in eating disorders. Arch Gen Psychiatry. 2003;60(2):179-83. [pmid: 12578435].
Kennedy SH, Goldbloom DS, Ralevski E, et al. Is there a role for selective monoamine oxidase inhibitor therapy in bulimia nervosa? A placebo-controlled trial of brofaromine. J Clin Psychopharmacol. 1993;13(6):415-22. [pmid: 8120155].
Klibanski A, Biller BM, Schoenfeld DA, et al. The effects of estrogen administration on trabecular bone loss in young women with anorexia nervosa. J Clin Endocrinol Metab. 1995;80(3):898-904. [pmid: 7883849].
Laederach-Hofmann K, Graf C, Horber F, et al. Imipramine and diet counseling with psychological support in the treatment of obese binge eaters: a randomized, placebo-controlled double-blind study. Int J Eat Disord. 1999;26(3):231-44. [pmid: 10441239].
Laessle RG, Beumont PJ, Butow P, et al. A comparison of nutritional management with stress management in the treatment of bulimia nervosa. Br J Psychiatry. 1991;159:250-61. [pmid: 1773242].
le Grange D, Eisler I, Dare C, et al. Evaluation of family treatments in adolescent anorexia nervosa: a pilot study. Int J Eat Disord. 1992;12(4):347-57.
Lee S, Chan YY, Hsu LK. The intermediate-term outcome of Chinese patients with anorexia nervosa in Hong Kong. Am J Psychiatry. 2003;160(5):967-72. [pmid: 12727702].
Lee S, Chan YY, Kwok K, et al. Relationship between control and the intermediate term outcome of anorexia nervosa in Hong Kong. Aust N Z J Psychiatry. 2005;39(3):141-5. [pmid: 15701062].
Levine MD, Marcus MD, Moulton P. Exercise in the treatment of binge eating disorder. Int J Eat Disord. 1996;19(2):171-7. [pmid: 8932555].
Lock J, Agras WS, Bryson S, et al. A comparison of short- and long-term family therapy for adolescent anorexia nervosa. J Am Acad Child Adolesc Psychiatry. 2005;44(7):632-9. [pmid: 15968231].
Löwe B, Zipfel S, Buchholz C, et al. Long-term outcome of anorexia nervosa in a prospective 21-year follow-up study. Psychol Med. 2001;31(5):881-90. [pmid: 11459385].
McElroy SL, Arnold LM, Shapira NA, et al. Topiramate in the treatment of binge eating disorder associated with obesity: a randomized, placebo-controlled trial. Am J Psychiatry. 2003;160(2):255-61. [pmid: 12562571].
McElroy SL, Casuto LS, Nelson EB, et al. Placebo-controlled trial of sertraline in the treatment of binge eating disorder. Am J Psychiatry. 2000;157(6):1004-6. [pmid: 10831483].
McElroy SL, Hudson JI, Malhotra S, et al. Citalopram in the treatment of binge-eating disorder: a placebo-controlled trial. J Clin Psychiatry. 2003;64(7):807-13. [pmid: 12934982].
McIntosh VV, Jordan J, Carter FA, et al. Three psychotherapies for anorexia nervosa: a randomized, controlled trial. Am J Psychiatry. 2005;162(4):741-7. [pmid: 15800147].
Miller KK, Grieco KA, Klibanski A. Testosterone administration in women with anorexia nervosa. J Clin Endocrinol Metab. 2005;90(3):1428-33. [pmid: 15613421].
Mitchell JE, Agras WS, Wilson GT, et al. A trial of a relapse prevention strategy in women with bulimia nervosa who respond to cognitive-behavior therapy. Int J Eat Disord. 2004;35(4):549-55. [pmid: 15101070].
Mitchell JE, Fletcher L, Hanson K, et al. The relative efficacy of fluoxetine and manual-based self-help in the treatment of outpatients with bulimia nervosa. J Clin Psychopharmacol. 2001;21(3):298-304. [pmid: 11386493].
Mitchell JE, Halmi K, Wilson GT, et al. A randomized secondary treatment study of women with bulimia nervosa who fail to respond to CBT. Int J Eat Disord. 2002;32(3):271-81. [pmid: 12210641].
Morgan HG, Purgold J, Welbourne J. Management and outcome in anorexia nervosa. A standardized prognostic study. Br J Psychiatry. 1983;143:282-7. [pmid: 6626842].
Møller-Madsen S, Nystrup J, Nielsen S. Mortality in anorexia nervosa in Denmark during the period 1970-1987. Acta Psychiatr Scand. 1996;94(6):454-9. [pmid: 9020999].
Nilsson EW, Gillberg C, Gillberg IC, et al. Ten-year follow-up of adolescent-onset anorexia nervosa: personality disorders. J Am Acad Child Adolesc Psychiatry. 1999;38(11):1389-95. [pmid: 10560225].
Patton GC. Mortality in eating disorders. Psychol Med. 1988;18(4):947-51. [pmid: 3270837].
Pearlstein T, Spurell E, Hohlstein LA, et al. A double-blind, placebo-controlled trial of fluvoxamine in binge eating disorder: a high placebo response. Arch Women Ment Health. 2003;6(2):147-51.
Pendleton VR, Goodrick GK, Poston WS, et al. Exercise augments the effects of cognitive-behavioral therapy in the treatment of binge eating. Int J Eat Disord. 2002;31(2):172-84. [pmid: 11920978].
Peterson CB, Mitchell JE, Engbloom S, et al. Group cognitive-behavioral treatment of binge eating disorder: a comparison of therapist-led versus self-help formats. Int J Eat Disord. 1998;24(2):125-36. [pmid: 9697011].
Peterson CB, Mitchell JE, Engbloom S, et al. Self-help versus therapist-led group cognitive-behavioral treatment of binge eating disorder at follow-up. Int J Eat Disord. 2001;30(4):363-74. [pmid: 11746298].
Pike KM, Walsh BT, Vitousek K, et al. Cognitive behavior therapy in the posthospitalization treatment of anorexia nervosa. Am J Psychiatry. 2003;160(11):2046-9. [pmid: 14594754].
Pillay M, Crisp AH. The impact of social skills training within an established in-patient treatment programme for anorexia nervosa. Br J Psychiatry. 1981;139:533-9. [pmid: 7037097].
Pinter O, Probst M, Vandereycken W, et al. The predictive value of body mass index for the weight evolution in anorexia nervosa. Eat Weight Disord. 2004;9(3):232-5. [pmid: 15656020].
Pope HG Jr, Keck PE Jr, McElroy SL, et al. A placebo-controlled study of trazodone in bulimia nervosa. J Clin Psychopharmacol. 1989;9(4):254-9. [pmid: 2671058].
Råstam M, Gillberg C, Wentz E. Outcome of teenage-onset anorexia nervosa in a Swedish community-based sample. Eur Child Adolesc Psychiatry. 2003;12(Suppl 1):I78-90. [pmid: 12567219].
Råstam M, Gillberg IC, Gillberg C. Anorexia nervosa 6 years after onset: Part II, Comorbid psychiatric problems. Compr Psychiatry. 1995;36(1):70-6. [pmid: 7705091].
Ricca V, Mannucci E, Mezzani B, et al. Fluoxetine and fluvoxamine combined with individual cognitive-behaviour therapy in binge eating disorder: a one-year follow-up study. Psychother Psychosom. 2001;70(6):298-306. [pmid: 11598429].
Ricca V, Mannucci E, Paionni A, et al. Venlafaxine versus fluoxetine in the treatment of atypical anorectic outpatients: a preliminary study. Eat Weight Disord. 1999;4(1):10-4. [pmid: 10728173].
Riva G, Bacchetta M, Baruffi M, et al. Virtual-reality-based multidimensional therapy for the treatment of body image disturbances in binge eating disorders: a preliminary controlled study. IEEE Trans Inf Technol Biomed. 2002;6(3):224-34. [pmid: 12381039].
Riva G, Bacchetta M, Cesa G, et al. Six-month follow-up of in-patient experiential cognitive therapy for binge eating disorders. Cyberpsychol Behav. 2003;6(3):251-8. [pmid: 12855080].
Robin AL, Siegel PT, Koepke T, et al. Family therapy versus individual therapy for adolescent females with anorexia nervosa. J Dev Behav Pediatr. 1994;15(2):111-6. [pmid: 8034762].
Robin AL, Siegel PT, Moye A. Family versus individual therapy for anorexia: impact on family conflict. Int J Eat Disord. 1995;17(4):313-22. [pmid: 7620470].
Robin AL, Siegel PT, Moye AW, et al. A controlled comparison of family versus individual therapy for adolescents with anorexia nervosa. J Am Acad Child Adolesc Psychiatry. 1999;38(12):1482-9. [pmid: 10596247].
Romano SJ, Halmi KA, Sarkar NP, et al. A placebo-controlled study of fluoxetine in continued treatment of bulimia nervosa after successful acute fluoxetine treatment. Am J Psychiatry. 2002;159(1):96-102. [pmid: 11772696].
Ruggiero GM, Laini V, Mauri MC, et al. A single blind comparison of amisulpride, fluoxetine and clomipramine in the treatment of restricting anorectics. Prog Neuropsychopharmacol Biol Psychiatry. 2001;25(5):1049-59. [pmid: 11444677].
Russell GF, Szmukler GI, Dare C, et al. An evaluation of family therapy in anorexia nervosa and bulimia nervosa. Arch Gen Psychiatry. 1987;44(12):1047-56. [pmid: 3318754].
Saccomani L, Savoini M, Cirrincione M, et al. Long-term outcome of children and adolescents with anorexia nervosa: study of comorbidity. J Psychosom Res. 1998;44(5):565-71. [pmid: 9623877].
Safer DL, Telch CF, Agras WS. Dialectical behavior therapy for bulimia nervosa. Am J Psychiatry. 2001;158(4):632-4. [pmid: 11282700].
Schork E, Eckert E, Halmi K. The relationship between psychopathology, eating disorder diagnosis, and clinical outcome at 10-year follow-up in anorexia nervosa. Compr Psychiatry. 1994;35:113-23. [pmid: 8187474].
Stice E, Fairburn CG. Dietary and dietary-depressive subtypes of bulimia nervosa show differential symptom presentation, social impairment, comorbidity, and course of illness. J Consult Clin Psychol. 2003;71(6):1090-4. [pmid: 14622085].
Strober M, Freeman R, Bower S, et al. Binge eating in anorexia nervosa predicts later onset of substance use disorder: a ten-year prospective, longitudinal follow-up of 95 adolescents. J Youth Adolesc. 1996;25(4):519-32.
Strober M, Freeman R, Morrell W. The long-term course of severe anorexia nervosa in adolescents: survival analysis of recovery, relapse, and outcome predictors over 10–15 years in a prospective study. Int J Eat Disord. 1997;22(4):339-60. [pmid: 9356884].
Stunkard A, Berkowitz R, Tanrikut C, et al. d-fenfluramine treatment of binge eating disorder. Am J Psychiatry. 1996;153(11):1455-9. [pmid: 8890680].
Sullivan PF, Bulik CM, Fear JL, et al. Outcome of anorexia nervosa: a case-control study. Am J Psychiatry. 1998;155(7):939-46. [pmid: 9659861].
Sundblad C, Landen M, Eriksson T, et al. Effects of the androgen antagonist flutamide and the serotonin reuptake inhibitor citalopram in bulimia nervosa: a placebo-controlled pilot study. J Clin Psychopharmacol. 2005;25(1):85-8. [pmid: 15643104].
Sundgot-Borgen J, Rosenvinge JH, Bahr R, et al. The effect of exercise, cognitive therapy, and nutritional counseling in treating bulimia nervosa. Med Sci Sports Exerc. 2002;34(2):190-5. [pmid: 11828224].
Szmukler GI, Young GP, Miller G, et al. A controlled trial of cisapride in anorexia nervosa. Int J Eat Disord. 1995;17(4):347-57. [pmid: 7620474].
Tanaka H, Kiriike N, Nagata T, et al. Outcome of severe anorexia nervosa patients receiving inpatient treatment in Japan: an 8-year follow-up study. Psychiatry Clin Neurosci. 2001;55(4):389-96. [pmid: 11442891].
Telch CF, Agras WS, Linehan MM. Dialectical behavior therapy for binge eating disorder. J Consult Clin Psychol. 2001;69(6):1061-5. [pmid: 11777110].
Thackwray DE, Smith MC, Bodfish JW, et al. A comparison of behavioral and cognitive-behavioral interventions for bulimia nervosa. J Consult Clin Psychol. 1993;61(4):639-45. [pmid: 8370859].
Thiels C, Schmidt U, Treasure J, et al. Guided self-change for bulimia nervosa incorporating use of a self-care manual. Am J Psychiatry. 1998;155(7):947-53. [pmid: 9659862].
Thien V, Thomas A, Markin D, et al. Pilot study of a graded exercise program for the treatment of anorexia nervosa. Int J Eat Disord. 2000;28(1):101-6. [pmid: 10800019].
Tolstrup K, Brinch M, Isager T, et al. Long-term outcome of 151 cases of anorexia nervosa. The Copenhagen Anorexia Nervosa Follow-Up Study. Acta Psychiatr Scand. 1985;71(4):380-7. [pmid: 4003103].
Treasure J, Schmidt U, Troop N, et al. Sequential treatment for bulimia nervosa incorporating a self-care manual. Br J Psychiatry. 1996;168(1):94-8. [pmid: 8770436].
Treasure J, Todd G, Brolly M, et al. A pilot study of a randomised trial of cognitive analytical therapy vs educational behavioral therapy for adult anorexia nervosa. Behav Res Ther. 1995;33(4):363-7. [pmid: 7755523].
Treasure JL, Katzman M, Schmidt U, et al. Engagement and outcome in the treatment of bulimia nervosa: first phase of a sequential design comparing motivation enhancement therapy and cognitive behavioural therapy. Behav Res Ther. 1999;37(5):405-18. [pmid: 10228313].
Turnbull SJ, Schmidt U, Troop NA, et al. Predictors of outcome for two treatments for bulimia nervosa: short and long-term. Int J Eat Disord. 1997;21(1):17-22. [pmid: 8986513].
Vandereycken W. Neuroleptics in the short-term treatment of anorexia nervosa. A double-blind placebo-controlled study with sulpiride. Br J Psychiatry. 1984;144:288-92. [pmid: 6367876].
Ventura M, Bauer B. Empowerment of women with purging-type bulimia nervosa through nutritional rehabilitation. Eat Weight Disord. 1999;4(2):55-62. [pmid: 11234243].
Walsh BT, Fairburn CG, Mickley D, et al. Treatment of bulimia nervosa in a primary care setting. Am J Psychiatry. 2004;161(3):556-61. [pmid: 14992983].
Walsh BT, Hadigan CM, Devlin MJ, et al. Long-term outcome of antidepressant treatment for bulimia nervosa. Am J Psychiatry. 1991;148(9):1206-12. [pmid: 1882999].
Walsh BT, Wilson GT, Loeb KL, et al. Medication and psychotherapy in the treatment of bulimia nervosa. Am J Psychiatry. 1997;154(4):523-31. [pmid: 9090340].
Wentz E, Gillberg C, Gillberg IC, et al. Ten-year follow-up of adolescent-onset anorexia nervosa: psychiatric disorders and overall functioning scales. J Child Psychol Psychiatry. 2001;42(5):613-22. [pmid: 11464966].
Wentz E, Gillberg IC, Gillberg C, et al. Ten-year follow-up of adolescent-onset anorexia nervosa: physical health and neurodevelopment. Dev Med Child Neurol. 2000;42(5):328-33. [pmid: 10855653].
Wilfley DE, Agras WS, Telch CF, et al. Group cognitive-behavioral therapy and group interpersonal psychotherapy for the nonpurging bulimic individual: a controlled comparison. J Consult Clin Psychol. 1993;61(2):296-305. [pmid: 8473584].
Wilfley DE, Friedman MA, Dounchis JZ, et al. Comorbid psychopathology in binge eating disorder: relation to eating disorder severity at baseline and following treatment. J Consult Clin Psychol. 2000;68(4):641-9. [pmid: 10965639].
Wilfley DE, Welch RR, Stein RI, et al. A randomized comparison of group cognitive-behavioral therapy and group interpersonal psychotherapy for the treatment of overweight individuals with binge-eating disorder. Arch Gen Psychiatry. 2002;59(8):713-21. [pmid: 12150647].
Wilson GT, Fairburn CC, Agras WS, et al. Cognitive-behavioral therapy for bulimia nervosa: time course and mechanisms of change. J Consult Clin Psychol. 2002;70(2):267-74. [pmid: 11952185].
Wilson GT, Loeb KL, Walsh BT, et al. Psychological versus pharmacological treatments of bulimia nervosa: predictors and processes of change. J Consult Clin Psychol. 1999;67(4):451-9. [pmid: 10450615].
Wolk SL, Devlin MJ. Stage of change as a predictor of response to psychotherapy for bulimia nervosa. Int J Eat Disord. 2001;30(1):96-100. [pmid: 11439413].