# References and Included Studies

1 Hoek H, van Hoeken D. Review of the prevalence and incidence of eating disorders. Int J Eat Disord. 2003;34:383-96. [pmid: 14566926].
2 Sullivan PF. Mortality in anorexia nervosa. Am J Psychiatry. 1995;152:1073-4. [pmid: 7793446].
3 Birmingham C, Su J, Hlynsky J, et al. The mortality rate from anorexia nervosa. Int J Eat Disord. 2005;38:143-6. [pmid: 16134111].
4 Watson TL, Andersen AE. A critical examination of the amenorrhea and weight criteria for diagnosing anorexia nervosa. Acta Psychiatr Scand. 2003;108(3):175-82. [pmid: 12890271].
5 Gendall K, Joyce P, Carter F, et al. The psychobiology and diagnostic significance of amenorrhea in anorexia nervosa. Fertility Sterility In Press.
6 Wonderlich S, Lilenfeld L, Riso L, et al. Personality and anorexia nervosa. Int J Eat Disord. 2005;37(Suppl):568-71.
7 Halmi K, Eckert E, Marchi P, et al. Comorbidity of psychiatric diagnoses in anorexia nervosa. Arch Gen Psychiatry. 1991;48:712-8. [pmid: 1883254].
8 Walters EE, Kendler KS. Anorexia nervosa and anorexic-like syndromes in a population-based female twin sample. Am J Psychiatry. 1995;152:64-71. [pmid: 7802123].
9 Bulik C, Sullivan P, Fear J, et al. Eating disorders and antecedent anxiety disorders: A controlled study. Acta Psychiatr Scand. 1997;96:101-7. [pmid: 9272193].
10 Kaye W, Bulik C, Thornton L, et al. Comorbidity of anxiety disorders with anorexia and bulimia nervosa. Am J Psychiatry. 2004;161:2215-21. [pmid: 15569892].
11 Sullivan PF, Bulik CM, Fear JL, et al. Outcome of anorexia nervosa. Am J Psychiatry. 1998;155:939-46. [pmid: 9659861].
12 Russell G. Anorexia nervosa and bulimia nervosa. In: Russell G, Hersov L, editors. Handbook of psychiatry 4: the neuroses and personality disorders. Cambridge: Cambridge University Press;1983.
13 Feighner J, Robins E, Guze S, et al. Diagnostic criteria for use in psychiatric research. Arch Gen Psychiatry. 1972;26:57-63. [pmid: 5009428].
14 American Psychiatric Association. Diagnostic and statistical manual of mental disorders. Third Edition. 3rd edition. Washington, DC: American Psychiatric Association Press; 1980.
15 American Psychiatric Association. Diagnostic and statistical manual of mental disorders. Edition III-R. 3rd, revised edition. Washington, DC: American Psychiatric Association Press; 1987.
16 American Psychiatric Association. Diagnostic and statistical manual of mental disorders. Fourth Edition. Washington, D.C.: American Psychiatric Association Press; 1994.
17 WHO. International statistical classification of diseases and related health problems, tenth revision. Geneva: World Health Organization; 1992.
18 McKnight Investigators. Risk factors for the onset of eating disorders in adolescent girls: results of the McKnight longitudinal risk factor study. Am J Psychiatry. 2003;160:248-54. [pmid: 12562570].
19 Wittchen HU, Nelson CB, Lachner G. Prevalence of mental disorders and psychosocial impairments in adolescents and young adults. Psychol Med. 1998;28(1):109-26. [pmid: 9483687].
20 Eagles J, Johnston M, Hunter D, et al. Increasing incidence of anorexia nervosa in the female population of northeast Scotland. Am J Psychiatry. 1995;152:1266-71. [pmid: 7653679].
21 Jones D, Fox M, Babigan H, et al. Epidemiology of anorexia nervosa in Monroe County, New York: 1960-76. Psychosom Medicine. 1980;42:551-8.
22 Lucas AR, Beard CM, O'Fallon WM, et al. Anorexia nervosa in Rochester, Minnesota: A 45-year study. Mayo Clin Proc. 1988;63:433-42. [pmid: 3361953].
23 Møller-Madsen S, Nystrup J. Incidence of anorexia nervosa in Denmark. Acta Psychiatr Scand. 1992;86:187-200.
24 Szmukler G. The epidemiology of anorexia nervosa and bulimia. J Psychiat Res. 1985;19:143-53. [pmid: 3876422].
25 Willi J, Grossman S. Epidemiology of anorexia nervosa in a defined region of Switzerland. Am J Psychiatry. 1983;140:564-7. [pmid: 6846583].
26 Milos G, Spindler A, Schnyder U, et al. Incidence of severe anorexia nervosa in Switzerland: 40 years of development. Int J Eat Disord. 2004;36:118-9. [pmid: 15185282].
27 Hall A, Hay P. Eating disorder patient referrals from a population region 1977-1986. Psychol Med. 1991;21:697-701. [pmid: 1946858].
28 Hoek H, Bartelds A, Bosveld J, et al. Impact of urbanization on detection rates of eating disorders. Am J Psychiatry. 1995;152:1272-8. [pmid: 7653680].
29 Joergensen J. The epidemiology of eating disorders in Fyn County Denmark, 1977-1986. Acta Psychiatr Scand. 1992;85:30-4. [pmid: 1546545].
30 Nielsen S. The epidemiology of anorexia nervosa in Denmark from 1973-1987: a nationwide register study of psychiatric admission. Acta Psychiatr Scand. 1990;81:507-14. [pmid: 2378240].
31 Willi J, Giacometti G, Limacher B. Update on the epidemiology of anorexia nervosa in a defined region of Switzerland. Am J Psychiatry. 1990;147(11):1514-7. [pmid: 2221165].
32 Lucas AR, Beard CM, O'Fallon WM, et al. 50-year trends in the incidence of anorexia nervosa in Rochester, Minn.: a population-based study. Am J Psychiatry. 1991;148:917-22. [pmid: 2053633].
33 Gowers S, Crisp A, Joughin N, et al. Premenarcheal anorexia nervosa. J Child Psychol Psychiatry. 1991;32:515-24. [pmid: 2061370].
34 Inagaki T, Horiguchi J, Tsubouchi K, et al. Late onset anorexia nervosa: two case reports. Int J Psychiatry Med. 2002;32:91-5. [pmid: 12075918].
35 Beck D, Casper R, Andersen A. Truly late onset of eating disorders: a study of 11 cases averaging 60 years of age at presentation. Int J Eat Disord. 1996;20(4):389-95. [pmid: 8953326].
36 Jacobi C, Hayward C, de Zwaan M, et al. Coming to terms with risk factors for eating disorders: application of risk terminology and suggestions for a general taxonomy. Psychol Bull. 2004;130:19-65. [pmid: 14717649].
37 Walsh B, Bulik C, Fairburn C et al. Defining eating disorders. Evans D, Foa E, Gur R et al. Treating and preventing adolescent mental health disorders: What we know and what we don't know. New York: Oxford University Press, The Annenberg Foundation Trust at Sunnylands, and the Annenberg Public Policy Center of the University of Pennsylvania;2005.
38 Cnattingius S, Hultman C, Dahl M, et al. Very preterm birth, birth trauma, and the risk of anorexia nervosa among girls. Arch Gen Psychiatry. 1999;56:634-8. [pmid: 10401509].
39 Lilenfeld L, Kaye W, Greeno C, et al. A controlled family study of restricting anorexia and bulimia nervosa: comorbidity in probands and disorders in first-degree relatives. Arch Gen Psychiatry. 1998;55:603-10. [pmid: 9672050].
40 Wade TD, Bulik CM, Neale M, et al. Anorexia nervosa and major depression: shared genetic and environmental risk factors. Am J Psychiatry. 2000;157(3):469-71. [pmid: 10698830].
41 Klump KL, Miller KB, Keel PK, et al. Genetic and environmental influences on anorexia nervosa syndromes in a population-based twin sample. Psychol Med. 2001;31(4):737-40. [pmid: 11352375].
42 Kortegaard LS, Hoerder K, Joergensen J, et al. A preliminary population-based twin study of self-reported eating disorder. Psychol Med. 2001;31(2):361-5. [pmid: 11232922].
43 Devlin B, Bacanu S, Klump K, et al. Linkage analysis of anorexia nervosa incorporating behavioral covariates. Hum Mol Genet. 2002;11(6):689-96. [pmid: 11912184].
44 Grice DE, Halmi KA, Fichter MM, et al. Evidence for a susceptibility gene for anorexia nervosa on chromosome 1. Am J Hum Genet. 2002;70(3):787-92. [pmid: 11799475]. [pmcid: 384957].
45 Bergen AW, van den Bree MBM, Yeager M, et al. Candidate genes for anorexia nervosa in the 1p33–36 linkage region: serotonin 1D and delta opioid receptor loci exhibit significant association to anorexia nervosa. Mol Psychiatry. 2003;8:397-406. [pmid: 12740597].
46 Slof-Op't Landt M, van Furth E, Meulenbelt I, et al. Eating Disorders: From Twin Studies to Candidate Genes and Beyond. Twin Res Hum Genet 16:467–82.
47 Kaye W, Frank G, Bailer U, et al. Neurobiology of anorexia nervosa: clinical implications of alterations of the function of serotonin and other neuronal systems. Int J Eat Disord. 2005;37:S15-9. [pmid: 15852312].
48 Barbarich N, Kaye W, Jimerson D. Neurotransmitter and imaging studies in anorexia nervosa: new targets for treatment. Curr Drug Targets CNS Neurol Disord. 2003;2:61-72. [pmid: 12769813].
49 Kaplan A. Medical aspects of anorexia nervosa and bulimia nervosa. Kennedy SH. Handbook of eating disorders. Toronto: University of Toronto;1993:22–9.
50 Katzman DK. Medical complications in adolescents with anorexia nervosa: a review of the literature. Int J Eat Disord. 2005;37(Suppl):S52-9. discussion S87–9. [pmid: 15852321].
51 Sharp C, Freeman C. The medical complications of anorexia nervosa. Br J Psychiatry. 1993;162:452-62. [pmid: 8481735].
52 Bulik C. Eating disorders in adolescents and young adults. Child Adolesc Psychiatr Clin N Am. 2002;11(2):201-18. [pmid: 12109318].
53 Harris EC, Barraclough B. Excess mortality of mental disorder. Br J Psychiatry. 1998;173:11-53. [pmid: 9850203].
54 Bulik C, Sullivan P, Fear J, et al. Fertility and reproduction in women with anorexia nervosa: a controlled study. J Clin Psychiatry. 1999;2:130-5. [pmid: 10084645].
55 Rigotti NA, Neer RM, Skates SJ, et al. The clinical course of osteoporosis in anorexia nervosa. A longitudinal study of cortical bone mass. J Am Med Assoc. 1991;265(9):1133-8.
56 Szmukler GI, Brown SW, Parsons V, et al. Premature loss of bone in chronic anorexia nervosa. Br Med J (Clin Res Ed). 1985;290(6461):26-7.
57 Gendall K, Bulik C. The long term biological consequences of anorexia nervosa. Current Nutrition and Food Science in press.
58 American Psychiatric Association Work Group on Eating Disorders. Practice guideline for the treatment of patients with eating disorders (revision). Am J Psychiatry. 2000;157(1 Suppl):1-39.
59 NICE. http://www.nice.org.uk/page.aspx?o=101239. National Institute for Clinical Excellence; 2004.
60 Golden N, Katzman D, Kreipe R, et al. Eating disorders in adolescents: position paper of the Society for Adolescent Medicine. J Adolesc Health. 2003;33:496-503. [pmid: 14642712].
61 American Academy of Pediatrics. Identifying and treating eating disorders. Pediatrics. 2003;111:204-11. [pmid: 12509579].
62 Beumont P, Hay P, Beumont D, et al. Royal Australian and New Zealand clinical practice guidelines for the treatment of anorexia nervosa. Aust N Z J Psychiatry. 2004;38(9):659-70. [pmid: 15324328].
63 Striegel-Moore RH, Leslie D, Petrill SA, et al. One-year use and cost of inpatient and outpatient services among female and male patients with an eating disorder: evidence from a national database of health insurance claims. Int J Eat Disord. 2000;27(4):381-9. [pmid: 10744844].
64 McKenzie JM, Joyce PR. Hospitalization for anorexia nervosa. Int J Eat Disord. 1992;11:235-41.
65 Matthias R. Care provision for patients with eating disorders in Europe: What patients get treatment where?. Eur Eat Disord Rev. 2005;13:159-68.
66 Agras W, Brandt H, Bulik C, et al. Report of the National Institutes of Health Workshop on Overcoming Barriers to Treatment Research in Anorexia Nervosa. Int J Eat Disord. 2004;35:509-21. [pmid: 15101067].
67 Anderson C, Bulik C. Gender differences in compensatory behaviors, weight and shape salience, and drive for thinness. Eating Behaviors 2003.
68 Lewinsohn P, Seeley J, Moerk K, et al. Gender differences in eating disorder symptoms in young adults. Int J Eat Disord. 2002;32:426-40. [pmid: 12386907].
69 Woodside DB, Garfinkel PE, Lin E, et al. Comparisons of men with full or partial eating disorders, men without eating disorders, and women with eating disorders in the community. Am J Psychiatry. 2001;158(4):570-4. [pmid: 11282690].
70 Fichter MM, Quadflieg N. Six-year course of bulimia nervosa. Int J Eat Disord. 1997;22(4):361-84. [pmid: 9356885].
71 Braun DL, Sunday SR, Halmi KA. Psychiatric comorbidity in patients with eating disorders. Psychol Med. 1994;24:859-67. [pmid: 7892354].
72 Brewerton T, Lydiard R, Herzog D, et al. Comorbidity of Axis I psychiatric disorders in bulimia nervosa. J Clin Psychiatry. 1995;56:77-80. [pmid: 7852257].
73 Bulik C, Sullivan P, Joyce P, et al. Lifetime comorbidity of alcohol dependence in women with bulimia nervosa. Addict Behav. 1997;22:437-46. [pmid: 9290854].
74 Bushnell JA, Wells E, McKenzie JM, et al. Bulimia comorbidity in the general population and in the clinic. Psychol Med. 1994;24:605-11. [pmid: 7991742].
75 Herzog DB, Keller MB, Sacks NR, et al. Psychiatric comorbidity in treatment-seeking anorexics and bulimics. J Am Acad Child Adolesc Psychiatry. 1992;31(5):810-8. [pmid: 1400111].
76 Perez M, Joiner TJ, Lewinsohn P. Is major depressive disorder or dysthymia more strongly associated with bulimia nervosa?. Int J Eat Disord. 2004;36:55-61. [pmid: 15185272].
77 Bulik C, Klump K, Thornton L, et al. Alcohol use disorder comorbidity in eating disorders: a multicenter study. J Clin Psychiatry. 2004;65:1000-6. [pmid: 15291691].
78 Bulik C, Sullivan P, Carter F, et al. Temperament, character, and personality disorder in bulimia nervosa. J Nerv Ment Dis. 1995;183:593-8. [pmid: 7561822].
79 Fassino S, Amianto F, Gramaglia C, et al. Temperament and character in eating disorders: ten years of studies. Eat Weight Disord. 2004;9:81-90. [pmid: 15330074].
80 Steiger H, Gauvin L, Israël M, et al. Serotonin function, personality-trait variations, and childhood abuse in women with bulimia-spectrum eating disorders. J Clin Psychiatry. 2004;65:830-7. [pmid: 15291661].
81 Bulik C, Sullivan P, Kendler K. Heritability of binge-eating and broadly defined bulimia nervosa. Biol Psychiatry. 1998;44(12):1210-8. [pmid: 9861464].
82 Wade T, Neale MC, Lake RIE, et al. A genetic analysis of the eating and attitudes associated with bulimia nervosa: Dealing with the problem of ascertainment. Behav Gen. 1999;29:1-10.
83 Bulik CM, Devlin B, Bacanu SA, et al. Significant linkage on chromosome 10p in families with bulimia nervosa. Am J Hum Genet. 2003;72(1):200-7. [pmid: 12476400]. [pmcid: 378626].
84 Frank G, Bailer U, Henry S, et al. Neuroimaging studies in eating disorders. CNS Spectr. 2004;9:539-48. [pmid: 15208513].
85 Walsh B, Devlin M. Eating disorders: progress and problems. Science. 1998;280:1387-90. [pmid: 9603723].
86 Mitchell J, Specker S, De Zwaan M. Comorbidity and medical complications of bulimia nervosa. J Clin Psychiatry. 1991;52:13-20. [pmid: 1938985].
87 Lasater L, Mehler P. Medical complications of bulimia nervosa. Eat Behav. 2001;2:279-92. [pmid: 15001037].
88 Fairburn C, Walsh B. Atypical eating disorders (eating disorders not otherwise specified). Fairburn C, Brownell K. Eating disorders and obesity: a comprehensive handbook. 2nd edition. New York: Guilford Press;2002:171–7.
89 Turner H, Bryant-Waugh R. Eating disorders not otherwise specified (EDNOS): profiles of clients presenting at a community eating disorders service. Eur Eat Disord Rev. 2003;12:18-26.
90 Stunkard AJ. Eating patterns and obesity. Psychiat Quarterly. 1959;33:284-95.
91 Walsh B. Diagnostic criteria for eating disorders in DSM-IV: Work in progress. Int J Eat Disord. 1992;11:301-4.
92 Spitzer RL, Yanovski S, Wadden T, et al. Binge eating disorders: its further validation in a multisite study. Int J Eat Disord. 1993;13(2):137-53. [pmid: 8477283].
93 Spitzer RL, Stunkard A, Yanovski S, et al. Binge eating disorder should be included in DSM- IV: A reply to Fairburn et al.'s “ The classification of recurrent overeating: the binge eating disorder proposal”. Int J Eat Disord. 1993;13(2):161-9. [pmid: 8477285].
94 Fairburn CG, Welch SL, Hay PJ. The classifaction of recurrent overeating: The “binge eating disorder” proposal. Int J Eat Disord. 1993;13(2):155-9. [pmid: 8477284].
95 Garfinkel P, Lin E, Goering P, et al. Bulimia nervosa in a Canadian community sample: prevalence and comparison of subgroups. Am J Psychiatry. 1995;152:1052-8. [pmid: 7793442].
96 Sullivan PF, Bulik CM, Kendler KS. The epidemiology and classification of bulimia nervosa. Psychol Med. 1998;28:599-610. [pmid: 9626716].
97 Hay P. The epidemiology of eating disorder behaviors: An Australian community-based survey. Int J Eat Disord. 1998;23:371-82. [pmid: 9561427].
98 Basdevant A, Pouillon M, Lahlou N, et al. Prevalence of binge eating disorder in different populations of french women. Int J Eat Disord. 1995;18:309-15. [pmid: 8580916].
99 Spitzer RL, Devlin M, Walsh TB, et al. Binge eating disorder: A multisite field trail of the diagnostic criteria. Int J Eat Disord. 1992;11(3):191-203.
100 Bruce B, Agras WS. Binge eating in females: A population-based investigation. Int J Eat Disord. 1992;12(4):365-73.
101 Bruce B, Wilfley D. Binge eating among the overweight population: a serious and prevalent problem. J Am Diet Assoc. 1996;96(1):58-61. [pmid: 8537571].
102 Yanovski S, Nelson J, Dubbert B, et al. Association of binge eating disorder and psychiatric comorbidity in obese subjects. Am J Psychiatry. 1993;150:1472-9. [pmid: 8379549].
103 Langer L, Warheit G, Zimmerman R. Epidemiological study of problem eating behaviors and related attitudes in the general population. Addict Behav. 1992;16:167-73. [pmid: 2063704].
104 Warheit G, Langer L, Zimmerman R, et al. Prevalence of bulimic behaviors and bulimia among a sample of the general population. Am J Epidemiol. 1993;137:569-76. [pmid: 8465808].
105 Bulik C, Sullivan P, Kendler K. Medical and psychiatric morbidity in obese women with and without binge eating. Int J Eat Disord. 2002;32:72-8. [pmid: 12183948].
106 Fairburn CG, Doll HA, Welch SL, et al. Risk factors for binge eating disorder: a community-based, case-control study. Arch Gen Psychiatry. 1998;55(5):425-32. [pmid: 9596045].
107 Hudson J, Lalonde J, Pindyck L, et al. Familial aggregation of binge-eating disorder. Arch Gen Psychiatry in press.
108 Reichborn-Kjennerud T, Bulik C, Tambs K, et al. Genetic and environmental influences on binge eating in the absence of compensatory behaviors: a population-based twin study. Int J Eat Disord. 2004;36:307-14. [pmid: 15478129].
109 Branson R, Potoczna N, Kral J, et al. Binge eating as a major phenotype of melanocortin 4 receptor gene mutations. N Engl J Med. 2003;348:1096-103. [pmid: 12646666].
110 Hebebrand J, Geller F, Dempfle A, et al. Binge-eating episodes are not characteristic of carriers of melanocortin-4 receptor gene mutations. Mol Psychiatry. 2004;9:796-800. [pmid: 15037865].
111 Brody ML, Walsh BT, Devlin MJ. Binge eating disorder: reliability and validity of a new diagnostic category. J Consult Clin Psychol. 1994;62(2):381-6. [pmid: 8201077].
112 de Zwaan M, Mitchell J, Seim H, et al. Eating related and general psychopathology in obese females with binge-eating disorder. Int J Eat Disord. 1994;15:43-52. [pmid: 8124326].
113 Wilson G. Relation of dieting and voluntary weight loss to psychological functioning and binge-eating. Ann Intern Med. 1993;119:727-30. [pmid: 8363206].
114 Marcus MD, Wing RR, Hopkins J. Obese binge eaters: affect, cognitions and response to behavioral weight control. J Consult Clin Psychol. 1988;56:433-9. [pmid: 3397436].
115 Mussell M, Mitchell J, de Zwaan M, et al. Clinical characteristics associated with binge eating in obese females: a descriptive study. Int J Obes Rel Metab Disord. 1996;20:324-31.
116 Fichter MM, Quadflieg N, Brandl B. Recurrent overeating: an empirical comparison of binge eating disorder, bulimia nervosa, and obesity. Int J Eat Disord. 1993;14(1):1-16. [pmid: 8339091].
117 de Zwaan M, Nutzinger D, Schoenbeck G. Binge eating in overweight women. Comprehen Psychiatry. 1992;33:256-61.
118 Wonderlich SA, de Zwaan M, Mitchell JE, et al. Psychological and dietary treatments of binge eating disorder: conceptual implications. Int J Eat Disord. 2003;34(Suppl):S58-73. [pmid: 12900987].
119 Carter W, Hudson J, Lalonde J, et al. Pharmacologic treatment of binge eating disorder. Int J Eat Disord. 2003;34:S74-88. [pmid: 12900988].
120 Lask B, Bryant-Waugh. Anorexia Nervosa and Related Eating Disorders in Children and Adolescence. Hove, East Sussex, UK: Psychology Press; 2000.
121 Hansen RA, Gartlehner G, Lohr KN, et al. Efficacy and safety of second-generation antidepressants in the treatment of major depressive disorder. Ann Intern Med. 2005;143(6):415-26. [pmid: 16172440].
122 West SL, King V, Carey TS et al. Systems to Rate the Strength of Scientific Evidence. Evidence Report, Technology Assessment No. 47. Rockville, Md.: Agency for Healthcare Research and Quality. AHRQ Publication No. 02-E016;2002.
123 Greer N, Mosser G, Logan G, et al. A practical approach to evidence grading. Joint Commision J Qual Improv. 2000;26:700-12.
124 Vandereycken W. Neuroleptics in the short-term treatment of anorexia nervosa. A double-blind placebo-controlled study with sulpiride. Br J Psychiatry. 1984;144:288-92. [pmid: 6367876].
125 Slade P, Russell G. Awareness of body dimensions in anorexia nervosa: cross-sectional and longitudinal studies. Psychol Med. 1973;3(2):188-99. [pmid: 4715850].
126 Deter H, Herzog W. The anorexia nervosa symptom score: a multidimensional tool for evaluating the course of anorexia nervosa. in: W. Herzog, Deter HC, Vandereycken W, eds. The Course of Eating Disorders: Long-term Follow-Up Studies of Anorexia and Bulimia Nervosa. New York: Springer;1992:40–52.
127 Parloff M, Kelman HC, Frank JD. Comfort, effectiveness, and self-awareness as criteria for improvement in psychotherapy. Am J Psychiatry. 1954;3:343-51. [pmid: 13197596].
128 Probst M, Vandereycken W, Van Coppenolle H, et al. Body size estimation in eating disorder patients: testing the video distortion method on a life-size screen. Behav Res Ther. 1995;33(8):985-90. [pmid: 7487859].
129 Beck A, Ward C, Mendelson M, et al. An inventory for measuring depression. Arch Gen Psychiatry. 1961;4:561-71. [pmid: 13688369].
130 Spitzer RL, Yanovski SZ, Marcus MD. Binge Eating Clinical Interview. Pittsburgh: HaPI Record; 1994.
131 Gormally J, Black S, Datson S, et al. The assessment of binge eating severity among obese persons. Addict Behav. 1982;7:47-55. [pmid: 7080884].
132 Rosen JC, Srebnik D, Salzberg E, Wendt S. Development of a body image avoidance questionnaire. Psychol Assess. 1991;3:32-7.
133 Henderson M, Freeman CP. Bulimic Investigation Test Edinburgh. Br J Psychiatry. 1987;150:18-24. [pmid: 3651670].
134 Derogatis L, Melisaratos N. The brief symptom inventory: an introductory report. Psychol Med. 1983;13(3):595-605. [pmid: 6622612].
135 Cooper P, Taylor M, Copper Z, et al. The development and validation of the Body Shape Questionnaire. Int J Eat Disord. 1987;6:485-94.
136 Dowson J, Henderson L. The validity of a short version of the Body Shape Questionnaire. Psychiatry Res. 2001;102(3):263-71. [pmid: 11440777].
137 Slade P, Dewey ME, Newton T, Brodie D, Gundi K. The development and preliminary validation of the body satisfaction scale. Psychol Health. 1990;4:213-20.
138 Franko D, Zuroff D, Rosenthal F. Construct validation of the Bulimic Thoughts Questionnaire. Society of Behavioral Medicine. 1986.
139 Achenbach T. Manual for the Child Behavior Checklist/4–18 and 1991 Profile. Burlington, VT: University of Vermont, Department of Psychiatry; 1991.
140 Crown S, Crisp AH. Manual of the Crown-Crisp Experiential Index. London: Hodder and Stoughton; 1979.
141 Kovacs M. The Children's Depression Inventory. Psychopharmacol Bull. 1985;21:995-8. [pmid: 4089116].
142 Thompson M, Gray JJ. Development and validation of a new body-image assessment scale. J Personality Assess. 1995;64(2):258-69.
143 Guy W. Assessment Manual for Psychopharmacology - Revised (DHEW Publ No ADM 76-338). 1976.
144 Welner Z, Reich W, Herjanic B, Jung K, Amado H. Reliability, validity, parent-child agreement studies of the diagnosis interview for children and adolescents (DICA). J Am Acad Child Adolesc Psychiatry. 1987;26:694-53. [pmid: 3667498].
145 Schlundt D, Zimering R. The Dieter's Inventory of Eating Temptations: A measure of weight control competence. Add Behav. 1988;13(2):151-64.
146 Johnson C. Initial consultation for patients with bulimia and anorexia nevosa. Garner D, Garfinkel PE. Handbook of Psychotherapy for Anorexia and Bulimia. New York: Guilford Press;1997:19–51.
147 Garner D, Olmsted M, Bohr Y, et al. The eating attitudes test: psychometric features and clinical correlates. Psychol Med. 1982;12(4):871-8. [pmid: 6961471].
148 Cooper Z, Cooper PJ, Fairburn CG. The validity of the eating disorder examination and its subscales. Br J Psychiatry. 1989;154:807-12. [pmid: 2597887].
149 Garner D, Olmsted MP, Polivy J. Development and validation of a multidimensional eating disorder inventory for anorexia nervosa and bulimia. Int J Eat Disord. 1983;2:15-34.
150 Garner D. Eating Disorder Inventory-2: Professional Manual. Odessa, FL: Psychological Assessment Resources, Inc; 1991.
151 Olson D, Sprenkle D, Russel C. Circumplex model of marital and family systems I: Cohesion and adaptability dimensions, family types and clinical applications. Fam Process. 1979;18:3-28. [pmid: 437067].
152 Skinner H, Steinhauer P, Santa-Barbara J. Family Assessment Measure - III Manual. Toronto Canada: Multi Health System, 1995.
153 Moos RH, MoosBS. Family Environment Scale Manual. Palo Alto, CA: Consulting Psychological Press; 1994.
154 Frost R, Marten PA, Lahart C, et al. The dimensions of perfectionism. Cognitive Therapy and Research. 1990;14:449-68.
155 Watson D, Friend R. Measure of socio-evaluative anxiety. J Consult Clin Psychol. 1969;33:448-57. [pmid: 5810590].
156 Watson D, Friend R. Measurement of social evaluative anxiety. J Consult Clin Psychol. 1969;33:448-57. [pmid: 5810590].
157 Leary M. A brief version of the Fear of Negative Evaluation Scale. Personality Soc Psychol. 1983;9:371-6.
158 Stunkard A, Sørensen T, Schlusinger F. Use of the Danish Adoption Register for the study of obesity and thinness. Res Publ Assoc Res Mental Dis. 1983;60:115-20.
159 Goldberg S, Halmi K, Eckert E, et al. Pretreatment predictors of outcome in anorexia nervosa. J Psychiatry Res. 1980;15:239-51.
160 Hamilton M. The assessment of anxiety states by rating. Br J Med Psychol. 1959;32:50-5. [pmid: 13638508].
161 Hamilton M. A rating scale for depression. J Neurol Neurosurg Psychiatry. 1960;23:56-62. [pmid: 14399272].
162 Shor R, Orne EC. The Harvard Group Scale of Hypnotic Susceptibility, Form A. Palo Alto, California: Consulting Psychological Press; 1962.
163 Luborsky. Principles of psychoanalytic psychotherapy. New York: Basic Books; 1984.
164 Robin A, Foster S. Negotiating parent adolescent conflict: A behavioral family systems approach. New York: Guilford Press; 1989.
165 Horowitz L, Rosenberg SE, Baer BA, Ureno G, Vilasenor VS. Inventory of Interpersonal Problems: Psychometric properties and clinical applications. J Consult Clin Psychol. 1988;56:885-92. [pmid: 3204198].
166 Craig A, Franklin J, Andrews G. A scale to measure locus of control of behaviour. Br J Med Psychol. 1984;57:173-80. [pmid: 6743598].
167 Keller M, Lavori PW, Friedman B, et al. The longitudinal follow-up evaluation. Arch Gen Psychiatry. 1987;44:540-8. [pmid: 3579500].
168 Millon. Millon Clinical Multiaxial Inventory manual. 3rd edition. Minneapolis, MN: Interpretive Scoring Systems; 1983.
169 Dahlstrom W, Welsh GS, Dahlstrom LE. An MMPI Handbook, Vol. 1 Clinical Interpretation. Rev. edition. Minneapolis, MN: University of Minnesota Press; 1972.
170 Hodgson R, Rachman SJ. Obsessional-compulsive complaints. Behav Res Therapy. 1977;15:389-95.
171 Morgan HG, Russell GF. Value of family background and clinical features as predictors of long-term outcome in anorexia nervosa: four-year follow-up study of 41 patients. 1975. 1975:355–71.
172 Morgan H, Hayward AE. Clinical assessment of anorexia nervosa: the Morgan-Russell outcome assessment schedule. Br J Psychiatry. 1988;152:367-71. [pmid: 3167372].
173 Vandenberg S, Kuse A. Mental rotation, a group test of three-dimensional spatial ability. Percept Mot Skills. 1978;47:509-604.
174 Robin A, Koepke T, Moye A. Multidimensional assessment of parent-adolescent relations. Psychol Assess. 1990;10:451-9.
175 Dupuy H. The Psychological General Well-Being (PGWB) Index. Wenger N, Mattson ME, Furberg CD, Elinson J, eds. Assessment of quality of life in clinical trials of cardiovascular therapies. New York: Le Jacq;1984:170–83.
176 Wing J, Cooper JE, Startorius N. The measurement and classification of psychiatric symptoms. Cambridge University Press; 1974.
177 Eddy K, Keel P, Dorer D, et al. Longitudinal comparison of anorexia nervosa subtypes. Int J Eat Disord. 2002;31(2):191-201. [pmid: 11920980].
178 Yanovski S. Binge eating disorder: Current knowledge and future directions. Obes Res. 1993;1:306-24. [pmid: 16350580].
179 Rathus S. A 30-item schedule for assessing assertive behavior. Behav Therap. 1973;4:398-406.
180 Rosenberg M. Society and the Adolescent Self-Image. Princeton, NJ: University Press; 1965.
181 Endicott J, Spitzer RL. A diagnostic interview: the schedule for affective disorders and schizophrenia. Arch Gen Psychiatry. 1978;35:837-44. [pmid: 678037].
182 Stanton A, Garcia M, Green S. Development and validation of the situation appetite measures. Add Behav. 1990;15(5):461-72.
183 Weissman M, Bothwell S. Assessment of social adjustment by patient self-report. Arch Gen Psychiatry. 1976;33:1111-5. [pmid: 962494].
184 Kinston W, Loader P. Eliciting whole-family interaction and a standardized clinical interview. J Fam Ther. 1984;6:347-63.
185 Shapiro DJ, Potkin SG, Jin Y, Brown B, Carreon D, Wu J. Measuring the psychological construct of control. Discriminant, divergent, and incremental validity of the Shapiro Control Inventory and Rotter's and Wallstons' Locus of Control Scales. Int J Psychosom. 1993;40(14):35-46. [pmid: 8070984].
186 First M, Spitzer RL, Gibbon M, Williams JBW. The structured clinical interview for DSM-IV Axis I Disorders. New York: State Psychiatric Institute, Biometrics Research Department; 1994.
187 Zung W. A self-rating depression scale. Arch Gen Psychiatry. 1965;12:63-70. [pmid: 14221692].
188 Ware J, Snow K, Kosinski M, Gandek B. SF-36 Health Survey: Manual and Interpretation Guide. 1993.
189 Fichter M, Elton M, Engel K, et al. Structured interview for anorexia and bulimia nervosa (SIAB): development of a new instrument for the assessment of eating disorders. Int J Eat Disord. 1991;10:571-92.
190 Angold A, Costello E, Messer S, et al. The development of a short questionnaire for use in epidemiological studies of depression in children and adolescents. Int J Meth Psychiat Res. 1995;5:237-49.
191 McConnaughy E, Prochaska J, Velicer W. Stages of change in psychotherapy: Measurement and sample profiles. Psychother: Theory Res Pract. 1983;20(3):368-75.
192 Rosenthal N, Bradt TH, Wehr TA. Seasonal Pattern Assessment Questionnaire. Washington DC: National Institute of Mental Health; 1987.
193 Spielberger C, Gorsuch R, Lushene R. Manual for the state-trait anxiety inventory. Palo Alto, CA: Consulting Psychologists Press; 1970.
194 Spielberger C. State-Trait Anger Expression Inventory. Tampa, FL: Psychological Assessment Resources, Inc., 1988.
195 Wolpe J. Psychotherapy by reciprocal inhibition. Stanford, CA: Stanford University Press; 1958.
196 Bagby M, Parker J, Taylor G. The twenty-item Toronto Alexithymia Scale - I. Item selection and cross-validation of the factor structure. J Psychosom Res. 1994;38:23-32. [pmid: 8126686].
197 Cloninger C, Svrakic DM, Przybeck TR. A psychobiological model of temperament and character. Arch Gen Psychiatry. 1993;50(12):975-90. [pmid: 8250684].
198 Stunkard A, Messick S. The three-factor eating questionnaire to measure dietary restraint, disinhibition and hunger. J Psychosom Res. 1985;29:71-83. [pmid: 3981480].
199 Wechsler D. Manual for the Wechsler Adult Intelligence Scale (WAIS). New York: Psychological Corporation, 1955.
200 Clark M, Abrams D, Niaura RS. Self-efficacy in weight management. J Consult Clin Psychol. 1991;59:739. [pmid: 1955608].
201 Boath E, Pryce A, Cox J. Social adjustment in childbearing women: the modified Work Leisure and Family Life Questionnaire. J Reproduct Infant Psychol. 1995;13(34):211-8.
202 Sunday S, Halmi KA, Einhorn A. The Yale-Brown-Cornell Eating Disorder Scale: A new scale to assess eating disorders symptomatology. Int J Eat Disord. 1995;18(3):237-45. [pmid: 8556019].
203 McElroy SL, Arnold LM, Shapira NA, et al. Topirmate in the treatment of binge eating disorder associated with obesity: a randomized placebo-controlled trial. Am J Psychiatry. 2003;160(2):255-61. [pmid: 12562571].
204 Goodman W, Price L, Rasmussen S, et al. The Yale-Brown Obsessive Compulsive Scale (Y-BOCS). Arch Gen Psychiatry. 1989;46:1006-11. [pmid: 2684084].
205 Achenbach T. Manual for the young adult self report and young adult behavior checklist. Burlington, VT: University of Vermont; 1997.
206 Attia E, Haiman C, Walsh BT, et al. Does fluoxetine augment the inpatient treatment of anorexia nervosa?. Am J Psychiatry. 1998;155(4):548-51. [pmid: 9546003].
207 Kaye WH, Nagata T, Weltzin TE, et al. Double-blind placebo-controlled administration of fluoxetine in restricting- and restricting-purging-type anorexia nervosa. Biol Psychiatry. 2001;49(7):644-52. [pmid: 11297722].
208 Halmi KA, Eckert E, LaDu TJ, et al. Anorexia nervosa. Treatment efficacy of cyproheptadine and amitriptyline. Arch Gen Psychiatry. 1986;43(2):177-81. [pmid: 3511877].
209 Biederman J, Herzog DB, Rivinus TM, et al. Amitriptyline in the treatment of anorexia nervosa: a double-blind, placebo-controlled study. J Clin Psychopharmacol. 1985;5(1):10-6. [pmid: 3973067].
210 Klibanski A, Biller BM, Schoenfeld DA, et al. The effects of estrogen administration on trabecular bone loss in young women with anorexia nervosa. J Clin Endocrinol Metab. 1995;80(3):898-904. [pmid: 7883849].
211 Miller KK, Grieco KA, Klibanski A. Testosterone administration in women with anorexia nervosa. J Clin Endocrinol Metab. 2005;90(3):1428-33. [pmid: 15613421].
212 Hill K, Bucuvalas J, McClain C, et al. Pilot study of growth hormone administration during the refeeding of malnourished anorexia nervosa patients. J Child Adolesc Psychopharmacol. 2000;10(1):3-8. [pmid: 10755576].
213 Birmingham CL, Goldner EM, Bakan R. Controlled trial of zinc supplementation in anorexia nervosa. Int J Eat Disord. 1994;15(3):251-5. [pmid: 8199605].
214 Barbarich NC, McConaha CW, Halmi KA, et al. Use of nutritional supplements to increase the efficacy of fluoxetine in the treatment of anorexia nervosa. Int J Eat Disord. 2004;35(1):10-5. [pmid: 14705152].
215 Ruggiero GM, Laini V, Mauri MC, et al. A single blind comparison of amisulpride, fluoxetine and clomipramine in the treatment of restricting anorectics. Prog Neuropsychopharmacol Biol Psychiatry. 2001;25(5):1049-59. [pmid: 11444677].
216 Brambilla F, Draisci A, Peirone A, et al. Combined cognitive-behavioral, psychopharmacological and nutritional therapy in eating disorders. 2. Anorexia nervosa--binge-eating/purging type. Neuropsychobiology. 1995;32(2):64-7. [pmid: 7477801].
217 Fassino S, Leombruni P, Daga G, et al. Efficacy of citalopram in anorexia nervosa: a pilot study. Eur Neuropsychopharmacol. 2002;12(5):453-9. [pmid: 12208563].
218 Szmukler GI, Young GP, Miller G, et al. A controlled trial of cisapride in anorexia nervosa. Int J Eat Disord. 1995;17(4):347-57. [pmid: 7620474].
219 Ricca V, Mannucci E, Paionni A, et al. Venlafaxine versus fluoxetine in the treatment of atypical anorectic outpatients: a preliminary study. Eat Weight Disord. 1999;4(1):10-4. [pmid: 10728173].
220 Birmingham CL, Gutierrez E, Jonat L, et al. Randomized controlled trial of warming in anorexia nervosa. Int J Eat Disord. 2004;35(2):234-8. [pmid: 14994363].
221 Eisler I, Dare C, Hodes M, et al. Family therapy for adolescent anorexia nervosa: the results of a controlled comparison of two family interventions. J Child Psychol Psychiatry. 2000;41(6):727-36. [pmid: 11039685].
222 Lock J, Agras WS, Bryson S, et al. A comparison of short- and long-term family therapy for adolescent anorexia nervosa. J Am Acad Child Adolesc Psychiatry. 2005;44(7):632-9. [pmid: 15968231].
223 Pike KM, Walsh BT, Vitousek K, et al. Cognitive behavior therapy in the posthospitalization treatment of anorexia nervosa. Am J Psychiatry. 2003;160(11):2046-9. [pmid: 14594754].
224 McIntosh VV, Jordan J, Carter FA, et al. Three psychotherapies for anorexia nervosa: a randomized, controlled trial. Am J Psychiatry. 2005;162(4):741-7. [pmid: 15800147].
225 Channon S, de Silva P, Hemsley D, et al. A controlled trial of cognitive-behavioural and behavioural treatment of anorexia nervosa. Behav Res Ther. 1989;27(5):529-35. [pmid: 2684134].
226 Treasure J, Todd G, Brolly M, et al. A pilot study of a randomised trial of cognitive analytical therapy vs educational behavioral therapy for adult anorexia nervosa. Behav Res Ther. 1995;33(4):363-7. [pmid: 7755523].
227 Crisp AH, Norton K, Gowers S, et al. A controlled study of the effect of therapies aimed at adolescent and family psychopathology in anorexia nervosa. Br J Psychiatry. 1991;159:325-33. [pmid: 1958942].
228 Dare C, Eisler I, Russell G, et al. Psychological therapies for adults with anorexia nervosa: randomised controlled trial of out-patient treatments. Br J Psychiatry. 2001;178:216-21. [pmid: 11230031].
229 Geist R, Heinmaa M, Stephens D, et al. Comparison of family therapy and family group psychoeducation in adolescents with anorexia nervosa. Can J Psychiatry. 2000;45(2):173-8. [pmid: 10742877].
230 Robin AL, Siegel PT, Koepke T, et al. Family therapy versus individual therapy for adolescent females with anorexia nervosa. J Dev Behav Pediatr. 1994;15(2):111-6. [pmid: 8034762].
231 Russell GF, Szmukler GI, Dare C, et al. An evaluation of family therapy in anorexia nervosa and bulimia nervosa. Arch Gen Psychiatry. 1987;44(12):1047-56. [pmid: 3318754].
232 Hall A, Crisp AH. Brief psychotherapy in the treatment of anorexia nervosa. Outcome at one year. Br J Psychiatry. 1987;151:185-91. [pmid: 3690108].
233 Pillay M, Crisp AH. The impact of social skills training within an established in-patient treatment programme for anorexia nervosa. Br J Psychiatry. 1981;139:533-9. [pmid: 7037097].
234 Thien V, Thomas A, Markin D, et al. Pilot study of a graded exercise program for the treatment of anorexia nervosa. Int J Eat Disord. 2000;28(1):101-6. [pmid: 10800019].
235 le Grange D, Eisler I, Dare C, et al. Evaluation of family treatments in adolescent anorexia nervosa: a pilot study. Int J Eat Disord. 1992;12(4):347-57.
236 Robin AL, Siegel PT, Moye AW, et al. A controlled comparison of family versus individual therapy for adolescents with anorexia nervosa. J Am Acad Child Adolesc Psychiatry. 1999;38(12):1482-9. [pmid: 10596247].
237 Robin AL, Siegel PT, Moye A. Family versus individual therapy for anorexia: impact on family conflict. Int J Eat Disord. 1995;17(4):313-22. [pmid: 7620470].
238 Gowers S, Norton K, Halek C, et al. Outcome of outpatient psychotherapy in a random allocation treatment study of anorexia nervosa. Int J Eat Disord. 1994;15(2):165-77. [pmid: 8173562].
239 Eisler I, Dare C, Russell G, et al. Family and individual therapy in anorexia nervosa. A 5-year follow-up. Arch Gen Psychiatry. 1997;54(11):1025-30. [pmid: 9366659].
240 Klerman G, Weissman M, Rounsaville B, Chevron E. Interpersonal Psychotherapy of Depression. New York, NY: Basic Books, Inc.; 1984.
241 Fairburn CG. Interpersonal psychotherapy for bulimia nervosa. In: Klerman G, Weissman M, editors. New Applications of Interpersonal Psychotherapy. Washington, DC: American Psychiatric Press;1993:355–78.
242 Lock J, le Grange D, Agras W, Dare C. Treatment manual for anorexia nervosa: A family-based approach. New York: Guilford Press; 2001.
243 Gartlehner G, Hansen RA, Kahwati L et al. Drug class review on second generation antidepressants: Updated report. Chapel Hill, NC: Prepared by RTI-UNC Evidence-based Practice Center for The Agency for Healthcare Research and Quality;2005.
244 Beumont PJ, Russell JD, Touyz SW, et al. Intensive nutritional counselling in bulimia nervosa: a role for supplementation with fluoxetine?. Aust N Z J Psychiatry. 1997;31(4):514-24. [pmid: 9272261].
245 Carruba MO, Cuzzolaro M, Riva L, et al. Efficacy and tolerability of moclobemide in bulimia nervosa: a placebo-controlled trial. Int Clin Psychopharmacol. 2001;16(1):27-32. [pmid: 11195257].
246 Faris PL, Kim SW, Meller WH, et al. Effect of decreasing afferent vagal activity with ondansetron on symptoms of bulimia nervosa: a randomised, double-blind trial. Lancet. 2000;355(9206):792-7. [pmid: 10711927].
247 Fichter MM, Kruger R, Rief W, et al. Fluvoxamine in prevention of relapse in bulimia nervosa: effects on eating-specific psychopathology. J Clin Psychopharmacol. 1996;16(1):9-18. [pmid: 8834413].
248 Fichter MM, Leibl K, Rief W, et al. Fluoxetine versus placebo: a double-blind study with bulimic inpatients undergoing intensive psychotherapy. Pharmacopsychiatry. 1991;24(1):1-7. [pmid: 2011615].
249 Fluoxetine Bulimia Nervosa Collaborative Study Group. Fluoxetine in the treatment of bulimia nervosa. A multicenter, placebo-controlled, double-blind trial. Fluoxetine Bulimia Nervosa Collaborative Study Group. Arch Gen Psychiatry. 1992;49(2):139-47. [pmid: 1550466].
250 Goldstein DJ, Wilson MG, Thompson VL, et al. Long-term fluoxetine treatment of bulimia nervosa. Fluoxetine Bulimia Nervosa Research Group. Br J Psychiatry. 1995;166(5):660-6. [pmid: 7620754].
251 Hoopes SP, Reimherr FW, Hedges DW, et al. Treatment of bulimia nervosa with topiramate in a randomized, double-blind, placebo-controlled trial, part 1: improvement in binge and purge measures. J Clin Psychiatry. 2003;64(11):1335-41. [pmid: 14658948].
252 Kanerva R, Rissanen A, Sarna S. Fluoxetine in the treatment of anxiety, depressive symptoms, and eating-related symptoms in bulimia nervosa. Nord J Psychiatry. 1994;49(7):237-42.
253 Kennedy SH, Goldbloom DS, Ralevski E, et al. Is there a role for selective monoamine oxidase inhibitor therapy in bulimia nervosa? A placebo-controlled trial of brofaromine. J Clin Psychopharmacol. 1993;13(6):415-22. [pmid: 8120155].
254 Romano SJ, Halmi KA, Sarkar NP, et al. A placebo-controlled study of fluoxetine in continued treatment of bulimia nervosa after successful acute fluoxetine treatment. Am J Psychiatry. 2002;159(1):96-102. [pmid: 11772696].
255 Pope HG Jr, Keck PE Jr, McElroy SL, et al. A placebo-controlled study of trazodone in bulimia nervosa. J Clin Psychopharmacol. 1989;9(4):254-9. [pmid: 2671058].
256 Sundblad C, Landen M, Eriksson T, et al. Effects of the androgen antagonist flutamide and the serotonin reuptake inhibitor citalopram in bulimia nervosa: a placebo-controlled pilot study. J Clin Psychopharmacol. 2005;25(1):85-8. [pmid: 15643104].
257 Walsh BT, Hadigan CM, Devlin MJ, et al. Long-term outcome of antidepressant treatment for bulimia nervosa. Am J Psychiatry. 1991;148(9):1206-12. [pmid: 1882999].
258 Goldstein DJ, Wilson MG, Ascroft RC, et al. Effectiveness of fluoxetine therapy in bulimia nervosa regardless of comorbid depression. Int J Eat Disord. 1999;25(1):19-27. [pmid: 9924649].
259 Hedges DW, Reimherr FW, Hoopes SP, et al. Treatment of bulimia nervosa with topiramate in a randomized, double-blind, placebo-controlled trial, part 2: improvement in psychiatric measures. J Clin Psychiatry. 2003;64(12):1449-54. [pmid: 14728106].
260 Agras WS, Rossiter EM, Arnow B, et al. Pharmacologic and cognitive-behavioral treatment for bulimia nervosa: a controlled comparison. Am J Psychiatry. 1992;149(1):82-7. [pmid: 1728190].
261 Goldbloom DS, Olmsted M, Davis R, et al. A randomized controlled trial of fluoxetine and cognitive behavioral therapy for bulimia nervosa: short-term outcome. Behav Res Ther. 1997;35(9):803-11. [pmid: 9299800].
262 Mitchell JE, Fletcher L, Hanson K, et al. The relative efficacy of fluoxetine and manual-based self-help in the treatment of outpatients with bulimia nervosa. J Clin Psychopharmacol. 2001;21(3):298-304. [pmid: 11386493].
263 Mitchell JE, Halmi K, Wilson GT, et al. A randomized secondary treatment study of women with bulimia nervosa who fail to respond to CBT. Int J Eat Disord. 2002;32(3):271-81. [pmid: 12210641].
264 Walsh BT, Wilson GT, Loeb KL, et al. Medication and psychotherapy in the treatment of bulimia nervosa. Am J Psychiatry. 1997;154(4):523-31. [pmid: 9090340].
265 Walsh BT, Fairburn CG, Mickley D, et al. Treatment of bulimia nervosa in a primary care setting. Am J Psychiatry. 2004;161(3):556-61. [pmid: 14992983].
266 Agras WS, Schneider JA, Arnow B, et al. Cognitive-behavioral and response-prevention treatments for bulimia nervosa. J Consult Clin Psychol. 1989;57(2):215-21. [pmid: 2708607].
267 Fairburn CG, Jones R, Peveler RC, et al. Psychotherapy and bulimia nervosa. Longer-term effects of interpersonal psychotherapy, behavior therapy, and cognitive behavior therapy. Arch Gen Psychiatry. 1993;50(6):419-28. [pmid: 8498876].
268 Wolk SL, Devlin MJ. Stage of change as a predictor of response to psychotherapy for bulimia nervosa. Int J Eat Disord. 2001;30(1):96-100. [pmid: 11439413].
269 Agras WS, Walsh T, Fairburn CG, et al. A multicenter comparison of cognitive-behavioral therapy and interpersonal psychotherapy for bulimia nervosa. Arch Gen Psychiatry. 2000;57(5):459-66. [pmid: 10807486].
270 Bulik CM, Sullivan PF, Carter FA, et al. The role of exposure with response prevention in the cognitive-behavioural therapy for bulimia nervosa. Psychol Med. 1998;28(3):611-23. [pmid: 9626717].
271 Bulik CM, Sullivan PF, Joyce PR, et al. Predictors of 1-year treatment outcome in bulimia nervosa. Compr Psychiatry. 1998;39(4):206-14. [pmid: 9675505].
272 Carter FA, McIntosh VV, Joyce PR, et al. Role of exposure with response prevention in cognitive-behavioral therapy for bulimia nervosa: three-year follow-up results. Int J Eat Disord. 2003;33(2):127-35. [pmid: 12616578].
273 Chen E, Touyz SW, Beumont PJ, et al. Comparison of group and individual cognitive-behavioral therapy for patients with bulimia nervosa. Int J Eat Disord. 2003;33(3):241-54. discussion 255–6. [pmid: 12655619].
274 Cooper PJ, Steere J. A comparison of two psychological treatments for bulimia nervosa: implications for models of maintenance. Behav Res Ther. 1995;33(8):875-85. [pmid: 7487847].
275 Davis R, McVey G, Heinmaa M, et al. Sequencing of cognitive-behavioral treatments for bulimia nervosa. Int J Eat Disord. 1999;25(4):361-74. [pmid: 10202647].
276 Fairburn C, Jones R, Peveler R, et al. Three psychological treatments for bulimia nervosa. A comparative trial. Arch Gen Psychiatry. 1991;48(5):463-9. [pmid: 2021299].
277 Fairburn C, Peveler R, Jones R, et al. Predictors of 12-month outcome in bulimia nervosa and the influence of attitudes to shape and weight. J Consult Clin Psychol. 1993;61(4):696-8. [pmid: 8370866].
278 Garner DM, Rockert W, Davis R, et al. Comparison of cognitive-behavioral and supportive-expressive therapy for bulimia nervosa. Am J Psychiatry. 1993;150(1):37-46. [pmid: 8417578].
279 Griffiths RA, Hadzi-Pavlovic D, Channon-Little L. A controlled evaluation of hypnobehavioural treatment for bulimia nervosa: immediate pre-post treatment effects. Eur Eat Disord Rev. 1994;2(4):202-20.
280 Hsu LK, Rand W, Sullivan S, et al. Cognitive therapy, nutritional therapy and their combination in the treatment of bulimia nervosa. Psychol Med. 2001;31(5):871-9. [pmid: 11459384].
281 Laessle RG, Beumont PJ, Butow P, et al. A comparison of nutritional management with stress management in the treatment of bulimia nervosa. Br J Psychiatry. 1991;159:250-61. [pmid: 1773242].
282 Safer DL, Telch CF, Agras WS. Dialectical behavior therapy for bulimia nervosa. Am J Psychiatry. 2001;158(4):632-4. [pmid: 11282700].
283 Sundgot-Borgen J, Rosenvinge JH, Bahr R, et al. The effect of exercise, cognitive therapy, and nutritional counseling in treating bulimia nervosa. Med Sci Sports Exerc. 2002;34(2):190-5. [pmid: 11828224].
284 Thackwray DE, Smith MC, Bodfish JW, et al. A comparison of behavioral and cognitive-behavioral interventions for bulimia nervosa. J Consult Clin Psychol. 1993;61(4):639-45. [pmid: 8370859].
285 Treasure JL, Katzman M, Schmidt U, et al. Engagement and outcome in the treatment of bulimia nervosa: first phase of a sequential design comparing motivation enhancement therapy and cognitive behavioural therapy. Behav Res Ther. 1999;37(5):405-18. [pmid: 10228313].
286 Ventura M, Bauer B. Empowerment of women with purging-type bulimia nervosa through nutritional rehabilitation. Eat Weight Disord. 1999;4(2):55-62. [pmid: 11234243].
287 Wilfley DE, Agras WS, Telch CF, et al. Group cognitive-behavioral therapy and group interpersonal psychotherapy for the nonpurging bulimic individual: a controlled comparison. J Consult Clin Psychol. 1993;61(2):296-305. [pmid: 8473584].
288 Wilson GT, Fairburn CC, Agras WS, et al. Cognitive-behavioral therapy for bulimia nervosa: time course and mechanisms of change. J Consult Clin Psychol. 2002;70(2):267-74. [pmid: 11952185].
289 Crosby RD, Mitchell JE, Raymond N, et al. Survival analysis of response to group psychotherapy in bulimia nervosa. Int J Eat Disord. 1993;13(4):359-68. [pmid: 8490638].
290 Bailer U, de Zwaan M, Leisch F, et al. Guided self-help versus cognitive-behavioral group therapy in the treatment of bulimia nervosa. Int J Eat Disord. 2004;35(4):522-37. [pmid: 15101068].
291 Carter JC, Olmsted MP, Kaplan AS, et al. Self-help for bulimia nervosa: a randomized controlled trial. Am J Psychiatry. 2003;160(5):973-8. [pmid: 12727703].
292 Durand MA, King M. Specialist treatment versus self-help for bulimia nervosa: a randomised controlled trial in general practice. Br J Gen Pract. 2003;53(490):371-7. [pmid: 12830564]. [pmcid: 1314596].
293 Thiels C, Schmidt U, Treasure J, et al. Guided self-change for bulimia nervosa incorporating use of a self-care manual. Am J Psychiatry. 1998;155(7):947-53. [pmid: 9659862].
294 Treasure J, Schmidt U, Troop N, et al. Sequential treatment for bulimia nervosa incorporating a self-care manual. Br J Psychiatry. 1996;168(1):94-8. [pmid: 8770436].
295 Braun DL, Sunday SR, Fornari VM, et al. Bright light therapy decreases winter binge frequency in women with bulimia nervosa: a double-blind, placebo-controlled study. Compr Psychiatry. 1999;40(6):442-8. [pmid: 10579376].
296 Esplen MJ, Garfinkel PE, Olmsted M, et al. A randomized controlled trial of guided imagery in bulimia nervosa. Psychol Med. 1998;28(6):1347-57. [pmid: 9854276].
297 Mitchell JE, Agras WS, Wilson GT, et al. A trial of a relapse prevention strategy in women with bulimia nervosa who respond to cognitive-behavior therapy. Int J Eat Disord. 2004;35(4):549-55. [pmid: 15101070].
298 Turnbull SJ, Schmidt U, Troop NA, et al. Predictors of outcome for two treatments for bulimia nervosa: short and long-term. Int J Eat Disord. 1997;21(1):17-22. [pmid: 8986513].
299 Fichter MM, Leibl C, Kruger R, et al. Effects of fluvoxamine on depression, anxiety, and other areas of general psychopathology in bulimia nervosa. Pharmacopsychiatry. 1997;30(3):85-92. [pmid: 9211569].
300 Agras WS, Rossiter EM, Arnow B, et al. One-year follow-up of psychosocial and pharmacologic treatments for bulimia nervosa. J Clin Psychiatry. 1994;55(5):179-83. [pmid: 8071266].
301 Wilson GT, Loeb KL, Walsh BT, et al. Psychological versus pharmacological treatments of bulimia nervosa: predictors and processes of change. J Consult Clin Psychol. 1999;67(4):451-9. [pmid: 10450615].
302 Fairburn CG. Overcoming Binge Eating. New York: Guilford; 1995.
303 Cooper P. Bulimia nervosa: a guide to recovery. London: Robinson; 1993.
304 Esplen M, Garfinkel PE. Guided imagery treatment to promote self-soothing in bulimia nervos: a theoretical rationale. J Psychother Pract Res. 1998;7:102-18. [pmid: 9527955].
305 Arnold LM, McElroy SL, Hudson JI, et al. A placebo-controlled, randomized trial of fluoxetine in the treatment of binge-eating disorder. J Clin Psychiatry. 2002;63(11):1028-33. [pmid: 12444817].
306 Hudson JI, McElroy SL, Raymond NC, et al. Fluvoxamine in the treatment of binge-eating disorder: a multicenter placebo-controlled, double-blind trial. Am J Psychiatry. 1998;155(12):1756-62. [pmid: 9842788].
307 Pearlstein T, Spurell E, Hohlstein LA, et al. A double-blind, placebo-controlled trial of fluvoxamine in binge eating disorder: a high placebo response. Arch Women Ment Health. 2003;6(2):147-51.
308 McElroy SL, Hudson JI, Malhotra S, et al. Citalopram in the treatment of binge-eating disorder: a placebo-controlled trial. J Clin Psychiatry. 2003;64(7):807-13. [pmid: 12934982].
309 McElroy SL, Casuto LS, Nelson EB, et al. Placebo-controlled trial of sertraline in the treatment of binge eating disorder. Am J Psychiatry. 2000;157(6):1004-6. [pmid: 10831483].
310 Laederach-Hofmann K, Graf C, Horber F, et al. Imipramine and diet counseling with psychological support in the treatment of obese binge eaters: a randomized, placebo-controlled double-blind study. Int J Eat Disord. 1999;26(3):231-44. [pmid: 10441239].
311 McElroy SL, Arnold LM, Shapira NA, et al. Topiramate in the treatment of binge eating disorder associated with obesity: a randomized, placebo-controlled trial. Am J Psychiatry. 2003;160(2):255-61. [pmid: 12562571].
312 Appolinario JC, Bacaltchuk J, Sichieri R, et al. A randomized, double-blind, placebo-controlled study of sibutramine in the treatment of binge-eating disorder. Arch Gen Psychiatry. 2003;60(11):1109-16. [pmid: 14609886].
313 Stunkard A, Berkowitz R, Tanrikut C, et al. d-fenfluramine treatment of binge eating disorder. Am J Psychiatry. 1996;153(11):1455-9. [pmid: 8890680].
314 Ricca V, Mannucci E, Mezzani B, et al. Fluoxetine and fluvoxamine combined with individual cognitive-behaviour therapy in binge eating disorder: a one-year follow-up study. Psychother Psychosom. 2001;70(6):298-306. [pmid: 11598429].
315 Grilo CM, Masheb RM, Wilson GT. Efficacy of cognitive behavioral therapy and fluoxetine for the treatment of binge eating disorder: a randomized double-blind placebo-controlled comparison. Biol Psychiatry. 2005;57(3):301-9. [pmid: 15691532].
316 Agras WS, Telch CF, Arnow B, et al. Weight loss, cognitive-behavioral, and desipramine treatments in binge eating disorder: an additive design. Behavior Therapy. 1994;25:225-38.
317 Grilo CM, Masheb RM, Salant SL. Cognitive behavioral therapy guided self-help and orlistat for the treatment of binge eating disorder: a randomized, double-blind, placebo-controlled trial. Biol Psychiatry. 2005;57(10):1193-201. [pmid: 15866560].
318 Wilfley DE, Welch RR, Stein RI, et al. A randomized comparison of group cognitive-behavioral therapy and group interpersonal psychotherapy for the treatment of overweight individuals with binge-eating disorder. Arch Gen Psychiatry. 2002;59(8):713-21. [pmid: 12150647].
319 Hilbert A, Tuschen-Caffier B. Body image interventions in cognitive-behavioural therapy of binge-eating disorder: a component analysis. Behav Res Ther. 2004;42(11):1325-39. [pmid: 15381441].
320 Gorin A, Le Grange D, Stone A. Effectiveness of spouse involvement in cognitive behavioral therapy for binge eating disorder. Int J Eat Disord. 2003;33(4):421-33. [pmid: 12658672].
321 Telch CF, Agras WS, Linehan MM. Dialectical behavior therapy for binge eating disorder. J Consult Clin Psychol. 2001;69(6):1061-5. [pmid: 11777110].
322 Agras WS, Telch CF, Arnow B, et al. Does interpersonal therapy help patients with binge eating disorder who fail to respond to cognitive-behavioral therapy?. J Consult Clin Psychol. 1995;63(3):356-60. [pmid: 7608347].
323 Eldredge KL, Stewart Agras W, Arnow B, et al. The effects of extending cognitive-behavioral therapy for binge eating disorder among initial treatment nonresponders. Int J Eat Disord. 1997;21(4):347-52. [pmid: 9138046].
324 Pendleton VR, Goodrick GK, Poston WS, et al. Exercise augments the effects of cognitive-behavioral therapy in the treatment of binge eating. Int J Eat Disord. 2002;31(2):172-84. [pmid: 11920978].
325 Riva G, Bacchetta M, Cesa G, et al. Six-month follow-up of in-patient experiential cognitive therapy for binge eating disorders. Cyberpsychol Behav. 2003;6(3):251-8. [pmid: 12855080].
326 Carter JC, Fairburn CG. Cognitive-behavioral self-help for binge eating disorder: a controlled effectiveness study. J Consult Clin Psychol. 1998;66(4):616-23. [pmid: 9735577].
327 Peterson CB, Mitchell JE, Engbloom S, et al. Self-help versus therapist-led group cognitive-behavioral treatment of binge eating disorder at follow-up. Int J Eat Disord. 2001;30(4):363-74. [pmid: 11746298].
328 Peterson CB, Mitchell JE, Engbloom S, et al. Group cognitive-behavioral treatment of binge eating disorder: a comparison of therapist-led versus self-help formats. Int J Eat Disord. 1998;24(2):125-36. [pmid: 9697011].
329 Levine MD, Marcus MD, Moulton P. Exercise in the treatment of binge eating disorder. Int J Eat Disord. 1996;19(2):171-7. [pmid: 8932555].
330 Riva G, Bacchetta M, Baruffi M, et al. Virtual-reality-based multidimensional therapy for the treatment of body image disturbances in binge eating disorders: a preliminary controlled study. IEEE Trans Inf Technol Biomed. 2002;6(3):224-34. [pmid: 12381039].
331 Schork E, Eckert E, Halmi K. The relationship between psychopathology, eating disorder diagnosis, and clinical outcome at 10-year follow-up in anorexia nervosa. Compr Psychiatry. 1994;35:113-23. [pmid: 8187474].
332 Gowers SG, Weetman J, Shore A, et al. Impact of hospitalisation on the outcome of adolescent anorexia nervosa. Br J Psychiatry. 2000;176:138-41. [pmid: 10755050].
333 Johnson C, Tobin DL, Dennis A. Differences in treatment outcome between borderline and nonborderline bulimics at one-year follow-up. Int J Eat Dis. 1990;9(6):617-27.
334 Herzog W, Deter HC, Fiehn W, et al. Medical findings and predictors of long-term physical outcome in anorexia nervosa: a prospective, 12-year follow-up study. Psychol Med. 1997;27(2):269-79. [pmid: 9089820].
335 Pinter O, Probst M, Vandereycken W, et al. The predictive value of body mass index for the weight evolution in anorexia nervosa. Eat Weight Disord. 2004;9(3):232-5. [pmid: 15656020].
336 Saccomani L, Savoini M, Cirrincione M, et al. Long-term outcome of children and adolescents with anorexia nervosa: study of comorbidity. J Psychosom Res. 1998;44(5):565-71. [pmid: 9623877].
337 Tolstrup K, Brinch M, Isager T, et al. Long-term outcome of 151 cases of anorexia nervosa. The Copenhagen Anorexia Nervosa Follow-Up Study. Acta Psychiatr Scand. 1985;71(4):380-7. [pmid: 4003103].
338 Eckert ED, Halmi KA, Marchi P, et al. Ten-year follow-up of anorexia nervosa: clinical course and outcome. Psychol Med. 1995;25(1):143-56. [pmid: 7792349].
339 Fichter MM, Quadflieg N. Six-year course and outcome of anorexia nervosa. Int J Eat Disord. 1999;26(4):359-85. [pmid: 10550777].
340 Isager T, Brinch M, Kreiner S, et al. Death and relapse in anorexia nervosa: survival analysis of 151 cases. J Psychiatr Res. 1985;19(23):515-21. [pmid: 4045762].
341 Strober M, Freeman R, Morrell W. The long-term course of severe anorexia nervosa in adolescents: survival analysis of recovery, relapse, and outcome predictors over 10–15 years in a prospective study. Int J Eat Disord. 1997;22(4):339-60. [pmid: 9356884].
342 Bulik CM, Sullivan PF, Fear JL, et al. Outcome of anorexia nervosa: eating attitudes, personality, and parental bonding. Int J Eat Disord. 2000;28(2):139-47. [pmid: 10897075].
343 Deter HC, Herzog W. Anorexia nervosa in a long-term perspective: results of the Heidelberg-Mannheim Study. Psychosom Med. 1994;56(1):20-7. [pmid: 8197311].
344 Gillberg C, Råstam M, Gillberg IC. Anorexia nervosa: physical health and neurodevelopment at 16 and 21 years. Dev Med Child Neurol. 1994;36(7):567-75. [pmid: 8034118].
345 Gillberg IC, Råstam M, Gillberg C. Anorexia nervosa outcome: six-year controlled longitudinal study of 51 cases including a population cohort. J Am Acad Child Adolesc Psychiatry. 1994;33(5):729-39. [pmid: 8056736].
346 Gillberg IC, Råstam M, Gillberg C. Anorexia nervosa 6 years after onset: Part I. Personality disorders. Compr Psychiatry. 1995;36(1):61-9. [pmid: 7705090].
347 Lee S, Chan YY, Hsu LK. The intermediate-term outcome of Chinese patients with anorexia nervosa in Hong Kong. Am J Psychiatry. 2003;160(5):967-72. [pmid: 12727702].
348 Löwe B, Zipfel S, Buchholz C, et al. Long-term outcome of anorexia nervosa in a prospective 21-year follow-up study. Psychol Med. 2001;31(5):881-90. [pmid: 11459385].
349 Råstam M, Gillberg C, Wentz E. Outcome of teenage-onset anorexia nervosa in a Swedish community-based sample. Eur Child Adolesc Psychiatry. 2003;12(Suppl 1):I78-90. [pmid: 12567219].
350 Sullivan PF, Bulik CM, Fear JL, et al. Outcome of anorexia nervosa: a case-control study. Am J Psychiatry. 1998;155(7):939-46. [pmid: 9659861].
351 Tanaka H, Kiriike N, Nagata T, et al. Outcome of severe anorexia nervosa patients receiving inpatient treatment in Japan: an 8-year follow-up study. Psychiatry Clin Neurosci. 2001;55(4):389-96. [pmid: 11442891].
352 Wentz E, Gillberg C, Gillberg IC, et al. Ten-year follow-up of adolescent-onset anorexia nervosa: psychiatric disorders and overall functioning scales. J Child Psychol Psychiatry. 2001;42(5):613-22. [pmid: 11464966].
353 Dancyger IF, Sunday SR, Eckert ED, et al. A comparative analysis of Minnesota Multiphasic Personality Inventory profiles of anorexia nervosa at hospital admission, discharge, and 10-year follow-up. Compr Psychiatry. 1997;38(3):185-91. [pmid: 9154376].
354 Hebebrand J, Himmelmann GW, Herzog W, et al. Prediction of low body weight at long-term follow-up in acute anorexia nervosa by low body weight at referral. Am J Psychiatry. 1997;154(4):566-9. [pmid: 9090350].
355 Morgan HG, Purgold J, Welbourne J. Management and outcome in anorexia nervosa. A standardized prognostic study. Br J Psychiatry. 1983;143:282-7. [pmid: 6626842].
356 Råstam M, Gillberg IC, Gillberg C. Anorexia nervosa 6 years after onset: Part II. Comorbid psychiatric problems. Compr Psychiatry. 1995;36(1):70-6. [pmid: 7705091].
357 Crisp AH, Callender JS, Halek C, et al. Long-term mortality in anorexia nervosa. A 20-year follow-up of the St George's and Aberdeen cohorts. Br J Psychiatry. 1992;161:104-7. [pmid: 1638303].
358 Strober M, Freeman R, Bower S, et al. Binge eating in anorexia nervosa predicts later onset of substance use disorder: a ten-year prospective, longitudinal follow-up of 95 adolescents. J Youth Adolesc. 1996;25(4):519-32.
359 Herzog W, Schellberg D, Deter HC. First recovery in anorexia nervosa patients in the long-term course: a discrete-time survival analysis. J Consult Clin Psychol. 1997;65(1):169-77. [pmid: 9103746].
360 Ivarsson T, Råstam M, Wentz E, et al. Depressive disorders in teenage-onset anorexia nervosa: a controlled longitudinal, partly community-based study. Compr Psychiatry. 2000;41(5):398-403. [pmid: 11011838].
361 Wentz E, Gillberg IC, Gillberg C, et al. Ten-year follow-up of adolescent-onset anorexia nervosa: physical health and neurodevelopment. Dev Med Child Neurol. 2000;42(5):328-33. [pmid: 10855653].
362 Nilsson EW, Gillberg C, Gillberg IC, et al. Ten-year follow-up of adolescent-onset anorexia nervosa: personality disorders. J Am Acad Child Adolesc Psychiatry. 1999;38(11):1389-95. [pmid: 10560225].
363 Lee S, Chan YY, Kwok K, et al. Relationship between control and the intermediate term outcome of anorexia nervosa in Hong Kong. Aust N Z J Psychiatry. 2005;39(3):141-5. [pmid: 15701062].
364 Møller-Madsen S, Nystrup J, Nielsen S. Mortality in anorexia nervosa in Denmark during the period 1970-1987. Acta Psychiatr Scand. 1996;94(6):454-9. [pmid: 9020999].
365 Deter HC, Schellberg D, Kopp W, et al. Predictability of a favorable outcome in anorexia nervosa. Eur Psychiatry. 2005;20(2):165-72. [pmid: 15797702].
366 Halvorsen I, Andersen A, Heyerdahl S. Good outcome of adolescent onset anorexia nervosa after systematic treatment. Intermediate to long-term follow-up of a representative county-sample. Eur Child Adolesc Psychiatry. 2004;13(5):295-306. [pmid: 15490277].
367 Ben-Tovim DI, Walker K, Gilchrist P, et al. Outcome in patients with eating disorders: a 5-year study. Lancet. 2001;357(9264):1254-7. [pmid: 11418150].
368 Franko DL, Keel PK, Dorer DJ, et al. What predicts suicide attempts in women with eating disorders?. Psychol Med. 2004;34(5):843-53. [pmid: 15500305].
369 Herzog DB, Dorer DJ, Keel PK, et al. Recovery and relapse in anorexia and bulimia nervosa: a 7.5-year follow-up study. J Am Acad Child Adolesc Psychiatry. 1999;38(7):829-37. [pmid: 10405500].
370 Herzog DB, Field AE, Keller MB, et al. Subtyping eating disorders: is it justified?. J Am Acad Child Adolesc Psychiatry. 1996;35(7):928-36. [pmid: 8768354].
371 Herzog DB, Greenwood DN, Dorer DJ, et al. Mortality in eating disorders: a descriptive study. Int J Eat Disord. 2000;28(1):20-6. [pmid: 10800010].
372 Keel PK, Dorer DJ, Eddy KT, et al. Predictors of mortality in eating disorders. Arch Gen Psychiatry. 2003;60(2):179-83. [pmid: 12578435].
373 Patton GC. Mortality in eating disorders. Psychol Med. 1988;18(4):947-51. [pmid: 3270837].
374 Herzog W, Deter HC. [Long-term follow-up: methodologic aspects in the interpretation of follow-up results. A presentation exemplified by anorexia nervosa]. 40. 1994:117–27.
375 Fairburn CG, Cooper Z, Doll HA, et al. The natural course of bulimia nervosa and binge eating disorder in young women. Arch Gen Psychiatry. 2000;57(7):659-65. [pmid: 10891036].
376 Fairburn CG, Norman PA, Welch SL, et al. A prospective study of outcome in bulimia nervosa and the long-term effects of three psychological treatments. Arch Gen Psychiatry. 1995;52(4):304-12. [pmid: 7702447].
377 Fairburn CG, Stice E, Cooper Z, et al. Understanding persistence in bulimia nervosa: a 5-year naturalistic study. J Consult Clin Psychol. 2003;71(1):103-9. [pmid: 12602430].
378 Fichter MM, Quadflieg N. Twelve-year course and outcome of bulimia nervosa. Psychol Med. 2004;34(8):1395-406. [pmid: 15724871].
379 Gendall KA, Bulik CM, Joyce PR, et al. Menstrual cycle irregularity in bulimia nervosa. Associated factors and changes with treatment. J Psychosom Res. 2000;49(6):409-15. [pmid: 11182433].
380 Herzog DB, Sacks NR, Keller MB, et al. Patterns and predictors of recovery in anorexia nervosa and bulimia nervosa. J Am Acad Child Adolesc Psychiatry. 1993;32(4):835-42. [pmid: 8340307].
381 Jäger B, Liedtke R, Lamprecht F, et al. Social and health adjustment of bulimic women 7–9 years following therapy. Acta Psychiatr Scand. 2004;110(2):138-45. [pmid: 15233714].
382 Keel PK, Mitchell JE, Davis TL, et al. Relationship between depression and body dissatisfaction in women diagnosed with bulimia nervosa. Int J Eat Disord. 2001;30(1):48-56. [pmid: 11439408].
383 Keel PK, Mitchell JE, Davis TL, et al. Impact of definitions on the description and prediction of bulimia nervosa outcome. Int J Eat Disord. 2000;28(4):377-86. [pmid: 11054784].
384 Keel PK, Mitchell JE, Miller KB, et al. Long-term outcome of bulimia nervosa. Arch Gen Psychiatry. 1999;56(1):63-9. [pmid: 9892257].
385 Keel PK, Mitchell JE, Miller KB, et al. Predictive validity of bulimia nervosa as a diagnostic category. Am J Psychiatry. 2000;157(1):136-8. [pmid: 10618030].
386 Stice E, Fairburn CG. Dietary and dietary-depressive subtypes of bulimia nervosa show differential symptom presentation, social impairment, comorbidity, and course of illness. J Consult Clin Psychol. 2003;71(6):1090-4. [pmid: 14622085].
387 Fichter MM, Quadflieg N, Gnutzmann A. Binge eating disorder: treatment outcome over a 6-year course. J Psychosom Res. 1998;44(34):385-405. [pmid: 9587882].
388 Wilfley DE, Friedman MA, Dounchis JZ, et al. Comorbid psychopathology in binge eating disorder: relation to eating disorder severity at baseline and following treatment. J Consult Clin Psychol. 2000;68(4):641-9. [pmid: 10965639].
389 Busetto L, Segato G, De Luca M, et al. Weight loss and postoperative complications in morbidly obese patients with binge eating disorder treated by laparoscopic adjustable gastric banding. Obes Surg. 2005;15(2):195-201. [pmid: 15802061].
390 Hay P, Bacaltchuk J, Claudino A, et al. Individual psychotherapy in the outpatient treatment of adults with anorexia nervosa. Cochrane Database Syst Rev 2003;(4):CD003909. DOI: 10.1002/14651858.
391 Hay P, Bacaltchuk J, Stefano S. Psychotherapy for bulimia nervosa and binging. Cochrane Database Syst Rev 2004;(3 ):CD000562. DOI: 10.1002/14651858.
392 Bacaltchuk J, Hay P. Antidepressants versus placebo for people with bulimia nervosa. Cochrane Database Syst Rev 2003;(4):CD003391. DOI: 10.1002/14651858.
393 Bacaltchuk J, Hay P, Trefiglio R. Antidepressants versus psychological treatments and their combination for bulimia nervosa. Cochrane Database Syst Rev 2001;4:CD003385. DOI: 10.1002/14651858.
394 Yanovski SZ, Yanovski JA. Obesity. N Engl J Med. 2002;346(8):591-602. [pmid: 11856799].
395 Halmi KA, Agras WS, Crow S, et al. Predictors of treatment acceptance and completion in anorexia nervosa: implications for future study designs. Arch Gen Psychiatry. 2005;62(7):776-81. [pmid: 15997019].
396 Mokdad AH, Bowman BA, Ford ES, et al. The continuing epidemics of obesity and diabetes in the United States. J Am Med Assoc. 2001;286(10):1195-200.
397 Flegal KM, Carroll MD, Ogden CL, et al. Prevalence and trends in obesity among US adults, 1999-2000. JAMA. 2002;288(14):1723-7. [pmid: 12365955].
398 National Task Force on the Prevention and Treatment of Obesity. Dieting and the development of eating disorders in overweight and obese adults. Arch Intern Med. 2000;160(17):2581-9. [pmid: 10999971].
399 Butryn ML, Wadden TA. Treatment of overweight in children and adolescents: does dieting increase the risk of eating disorders?. Int J Eat Disord. 2005;37(4):285-93. [pmid: 15856498].
400 Wadden TA, Foster GD, Sarwer DB et al. Dieting and the development of eating disorders in obese women: results of a randomized controlled trial. 80. 2004:560–8.
401 Neumark-Sztainer D. Can we simultaneously work toward the prevention of obesity and eating disorders in children and adolescents?. Int J Eat Disord. 2005;38(3):220-7. [pmid: 16211633].