# Executive Summary

## Introduction

The RTI International-University of North Carolina at Chapel Hill Evidence-based Practice Center (RTI-UNC EPC) conducted a systematic review of the literature on key questions concerning anorexia nervosa (AN), bulimia nervosa (BN), and eating disorders not otherwise specified (EDNOS) (focusing on binge eating disorder [BED]) to address questions posed by the American Psychiatric Association and Laureate Psychiatric Hospital through the Agency for Healthcare Research and Quality (AHRQ). Funding was provided by AHRQ, the Office of Research on Women's Health at the National Institutes of Health, and the Health Resources and Services Administration. We received guidance and input from a Technical Expert Panel (TEP).

We systematically reviewed the evidence on two categories of issues—treatment and outcomes for AN, BN, and BED—in six key questions (KQs): (1) efficacy of treatment, (2) harms associated with treatment, (3) factors associated with the efficacy of treatment, (4) whether efficacy of treatment differs by sex, gender, age, race, ethnicity, or cultural group, (5) factors associated with outcomes, and (6) whether outcomes differ by sex, gender, age, race, ethnicity, or cultural group.

AN is marked by low body weight, fear of weight gain, disturbance in the way in which one's body size is perceived, denial of illness, or undue influence of weight on self-evaluation. Although amenorrhea is a diagnostic criterion, it is of questionable relevance.

BN is characterized by recurrent episodes of binge eating in combination with some form of compensatory behavior. Binge eating is the consumption of an uncharacteristically large amount of food by social comparison coupled with a feeling of being out of control. Compensatory behaviors include self-induced vomiting; misuse of laxatives, diuretics, or other agents; fasting; and excessive exercise.

BED is marked by binge eating in the absence of compensatory behaviors, a series of associated features of binge eating, and marked distress regarding binge eating. Overweight and obesity are commonly seen in individuals with BED.

Although rigorous epidemiologic data are lacking in the United States, the mean prevalence of AN is 0.3 percent, of subthreshold AN 0.37 percent to 1.3 percent, of BN 1.0 percent, and of BED 0.7 percent to 3.0 percent. Mortality from AN is about 5 percent per decade of followup. Treatment for severe AN can involve inpatient or partial hospitalization in costly specialized settings. Inadequate insurance coverage often truncates the recommended duration of treatment. Treatment costs for AN are higher than those for obsessive-compulsive disorder and comparable to those for schizophrenia. In contrast, treatment for BN in the United States is typically on an outpatient basis.

## Methods

We searched MEDLINE®, the Cumulative Index to Nursing and Applied Health (CINAHL), PSYCHINFO, the Educational Resources Information Center (ERIC), the National Agricultural Library (AGRICOLA), and Cochrane Collaboration libraries. Based on key questions and discussion with our TEP, we generated a list of article inclusion and exclusion criteria. We reviewed studies of humans, ages 10 years and older, of both sexes, published in all languages and from all nations, from 1980 to September 2005. Studies had to include populations diagnosed primarily with AN, BN, or BED and to report on at least one of our outcomes categories of interest: eating-related behaviors, psychiatric and psychological outcomes, and biomarker measures. We reviewed each abstract and article systematically against a priori criteria to determine whether to include it in the review. One reviewer initially evaluated abstracts for inclusion or exclusion. If that reviewer concluded that the article should be included in the review, it was retained. Articles that the reviewer determined did not meet our criteria were re-reviewed by a senior reviewer who could include the article if she disagreed with the initial determination. We assigned each excluded article a reason for exclusion.

The RTI-UNC EPC team abstracted data from included articles directly into evidence tables. For both the treatment and the outcomes literatures, a primary reviewer abstracted data directly into evidence tables; a second (senior) reviewer confirmed accuracy, completeness, and consistency. The two staff reconciled all disagreements about information in evidence tables.

Each abstractor independently evaluated study quality. Because of differences in the treatment and outcomes literature, we evaluated the two bodies of literature using separate criteria. For the treatment literature, our evaluation used 25 items in 11 categories: (1) research aim/study question, (2) study population, (3) randomization, (4) blinding, (5) interventions, (6) outcomes, (7) statistical analysis, (8) results, (9) discussion, (10) external validity, and (11) funding/sponsorship. For the outcomes literature, we evaluated the evidence against 17 items in 8 categories: (1) research aim/study question, (2) study population, (3) eating disorder diagnosis method, (4) study design, (5) statistical analysis, (6) results/outcome measurement, (7) external validity, and (8) discussion.

We focused our analysis on studies that received fair or good quality ratings. This included 19 studies discussed in 22 articles concerning treatment for AN: 38 studies discussed in 48 articles concerning treatment for BN: 20 studies discussed in 21 articles concerning treatment for BED: 26 studies discussed in 32 articles concerning outcomes for AN: 9 studies discussed in 13 articles concerning outcomes for BN: 7 studies discussed in 7 articles concerning outcomes for both AN and BN: and 3 studies discussed in 3 articles concerning outcomes for BED.

## Results

### Treatment Studies

Anorexia Nervosa. We divided the treatment literature into medication-only (generally in the context of clinical management or hospitalization), medication plus behavioral intervention, and behavioral intervention only for either adults or adolescents. The literature regarding medication treatments for AN is sparse and inconclusive. The vast majority of studies had small sample sizes and rarely had adequate statistical power to allow for definitive conclusions. Although studies did include medication administered during or after inpatient intervention, no AN studies that systematically combined medication with behavioral interventions met our inclusion criteria, revealing a substantial gap in the literature.

In the behavioral intervention literature, preliminary evidence suggests that cognitive behavioral therapy (CBT) may reduce relapse risk for adults with AN after weight restoration. Sufficient evidence does not exist to determine whether CBT has any effect during the acute phase of the illness, and one study, also requiring replication, showed that a manual-based treatment combining elements of sound clinical management and supportive psychotherapy by a specialist was more effective than CBT during the acute phase. Family therapy as currently conceptualized does not appear to be effective with adults with AN with longer duration of illness. Specific forms of family therapy initially focusing on parental control of renutrition is efficacious in treating AN in adolescents and leads to clinically meaningful weight gain and psychological change. The lack of follow-up data compromises our ability to determine the extent to which treatment gains are maintained.

Bulimia Nervosa. In medication trials, fluoxetine (60 mg/day) administered for 6 weeks to 18 weeks reduced the core bulimia symptoms of binge eating and purging and associated psychological features in the short term. The 60 mg dose performs better than lower doses and is associated with prevention of relapse at 1 year. Evidence for the long-term effectiveness of relatively brief medication treatment does not exist. The optimal duration of treatment and the optimal strategy for maintenance of treatment gains are unknown.

Studies that combine drugs and behavioral interventions provide only preliminary evidence regarding the optimal combination of medication and psychotherapy or self-help. How best to treat individuals who do not respond to CBT or fluoxetine remains a major shortcoming of the literature. For behavioral interventions for BN, CBT administered individually or in group format is effective in reducing the core behavioral symptoms of binge eating and purging and psychological features in both the short and long term. Further evidence is required to establish the role for self-help in reducing bulimic behaviors.

Binge Eating Disorder. For BED, we addressed two critical outcomes—decrease in binge eating and decrease in weight in overweight individuals. Various medications were studied, including selective serotonin reuptake inhibitors (SSRIs); a combined serotonin, dopamine, and norepinephrine uptake inhibitor; tricyclic antidepressants; an anticonvulsant; and one appetite suppressant. In short-term trials, SSRIs led to greater rates of reduction in target eating, psychiatric and weight symptoms, and severity of illness than placebo controls. However, in the absence of clear endpoint data, and in the absence of data regarding abstinence from binge eating, we cannot judge the magnitude of the clinical impact of these interventions. Moreover, in the absence of follow-up data after drug discontinuation, we do not know whether observed changes in binge eating, depression, and weight persist.

The combination of CBT plus medication may improve both binge eating and weight loss, although sufficient trials have not been done to determine definitively which medications are best at producing and maintaining weight loss. Moreover, the optimal duration of medication treatment for sustained weight loss has not yet been addressed empirically.

Collectively, clinical trials incorporating CBT for BED indicated that CBT decreases either the number of binge days or the actual number of reported binge episodes. CBT leads to greater rates of abstinence than does a waiting list control approach when administered either individually or in group format, and this abstinence persists for up to 4 months posttreatment. CBT also improves the psychological aspects of BED, such as ratings of restraint, hunger, and disinhibition. Results are mixed as to whether CBT improves self-rated depression in this population. Finally, CBT does not appear to produce decreases in weight.

Various forms of self-help were efficacious in decreasing binge days, binge eating episodes, and psychological features associated with BED. Self-help also led to greater abstinence from binge eating than waiting list; short-term abstinence rates approximate those seen in face-to-face psychotherapy trials.

Strength of Evidence in Treatment Literature. We graded the strength of the body of evidence for each question separately. For efficacy of treatment (KQ 1), we graded evidence for AN treatment as weak, that for BN medication and behavioral interventions as strong, and that for BED therapies as moderate. For harms associated with treatment (KQ 2), we graded medication interventions for BN and BED as consistently strong; the literatures for all AN interventions and all other BN and BED interventions were graded as weak to nonexistent because many studies failed to address harms associated with treatment. For factors associated with efficacy of treatment (KQ 3), with the exception of behavioral interventions for BN, which we graded as moderate, we graded the literature uniformly as weak. No published literature provided evidence on whether the efficacy of treatment for these conditions differs by sociodemographic factors (KQ 4). Overall, the literature on the treatment of AN in particular was deficient.

### Outcomes Literature

Outcomes of Eating Disorders. One prospective cohort study, conducted in Sweden, followed individuals with AN in the community. Over a 10-year period, approximately half of the group had fully recovered; a small percentage continued to suffer from AN, and the remainder still had other eating disorders. Members of the AN group no longer differed from those in the comparison group in terms of weight, but they continued to be more depressed and to suffer from a variety of personality disorders, obsessive-compulsive disorder, Asperger syndrome, and autism spectrum disorders.

The remaining AN studies followed patient populations. Typically, at least one-half of the patients no longer suffered from AN at followup. However, many continued to have other eating disorders such as BN or EDNOS, and mortality was significantly higher than would be expected in the population matched by sex and age. Factors associated with recovery or good outcomes included lower levels of depression and compulsivity. Factors associated with increased mortality included concurrent alcohol and substance use disorders.

All of the BN outcomes studies followed patient populations. This literature emphasizes comparisons of various definitions of disease outcomes and diagnostic subtypes. Generally, more than one-half of the patients followed no longer had a BN diagnosis at the end of the study. A substantial percentage continued to suffer from other eating disorders, but BN was not associated with an increased mortality risk. A limited number of analyses uncovered factors significantly associated with outcomes of this disease, but only depression was consistently associated with worse outcomes.

Only sparse evidence addresses factors associated with BED outcomes. The three included studies have vastly different designs and research questions; more importantly, they do not converge on any systematic findings. Recalling that no studies of EDNOS outcomes exist, we conclude that the literature regarding outcomes of both EDNOS in general and BED in particular is seriously lacking; we believe that no conclusions can be drawn about factors influencing outcomes of these disorders.

Age of AN disease onset was examined in several AN outcomes studies. However, the relation between this variable and outcomes was mixed. No additional differences by participant sex, gender, age, race, ethnicity, or cultural group emerged from the AN, BN, or BED outcomes literature.

Strength of Evidence in Outcomes Literature. The strength of the evidence addressing factors associated with outcomes among individuals with AN and BN is moderate. In contrast, given the limited information about factors related to outcomes among individuals with BED (KQ 5), we rated BED evidence as weak. We used the body of literature concerning KQ 5 to examine differences in outcomes by sociodemographic factors (KQ 6). We graded the AN literature as weak and the BN and BED literature as nonexistent.

## Discussion

In conclusion, the literature regarding treatment efficacy and outcome for AN, BN, and BED is of highly variable quality. In the treatment literature, the largest deficiency rests with treatment efficacy for AN where the literature was weakest. Future studies require large numbers of participants, multiple sites, appropriate biomarker outcomes, and clear delineation of the age of participants. For BN, future studies should address novel treatments for the disorder, optimal duration of intervention, and optimal approaches for those who do not respond to medication or CBT. For BED, future studies should identify interventions that are effective for both elimination of binge eating and reduction of weight (in overweight individuals), optimal duration of intervention, and effective strategies for prevention of relapse. For all three disorders, exploration of additional treatment approaches is warranted. In addition, for all three disorders, greater attention must be paid to factors influencing outcomes, harms associated with treatment, and differential efficacy by sex, gender, age, race, ethnicity, or cultural group.

For all three disorders, consensus definitions of remission, recovery, and relapse are essential. Greater attention to disease presentations currently grouped under the heading of EDNOS is required for both treatment and outcome literature. For outcome studies, especially for BN and BED, population-based cohort studies with comparison groups and adequate durations of followup are required. For both future treatment and outcome studies, researchers must carefully attend to issues of statistical power, research design including the use of similar outcome measures across studies, and sophistication and appropriateness of statistical analyses.