# Discussion

This chapter discusses our findings about anorexia nervosa (AN), bulimia nervosa (BN), and binge eating disorder (BED), which derive from our systematic review of literature for six key questions (KQs). Four KQs dealt with evidence about treatment issues (Chapters 3, 4, and 5):

1 Efficacy of treatments or combination of treatments
2 Harms associated with the treatment or combination of treatments
3 Factors associated with the efficacy of treatment
4 Differences in efficacy of treatment by sex, gender, age, race, ethnicity, or cultural group.
  Two other KQs covered the course and outcomes of these conditions (Chapter 6):
5 Factors associated with outcomes among individuals with these conditions
6 Differences in outcomes by sex, gender, age, race, ethnicity, or cultural group.

Our report focused on randomized controlled trials (RCTs) for AN, BN, and BED and on outcomes studies that included sample sizes of 50 or greater and included at least 1 year of follow-up. All studies were published since 1980.

In this chapter, we first review the quality of the literature and the strength of the evidence based on the outcomes of and treatment of eating disorders. The confidence that readers can have in our findings, conclusions, inferences, and research recommendations rests heavily on the quality of the research reviewed and the overall robustness of the evidence. We then discuss the major issues resolved (or not resolved) in treating and managing patients with these conditions, drawing as appropriate from the findings for all six questions. Following that section, we present our research recommendations. The chapter ends with a brief recapitulation of our conclusions.

## Critical Findings and Implications for Treatment of Eating Disorders

In this section we review our main findings on treatments for AN, BN, and BED, with specific attention to medications only, behavioral or psychotherapy interventions only, combination approaches, and novel interventions. We also comment on issues relating to outcomes from the disorders, including mortality. Before presenting the findings, we document our approach to assessing the strength of these bodies of evidence. Interpreting our findings accurately requires appreciation of the considerable drawbacks to much of this literature.

### Quality of Literature and Strength of Evidence

As described in Chapter 2 and documented in both evidence and summary tables, we first applied rigorous selection criteria for articles and assessed the quality of each study. We then evaluated the strength of the bodies of evidence available to address each KQ for each disorder. The possible grades in our scheme are as follows:

I Strong evidence. The evidence is from studies of strong design; results are both clinically important and consistent with minor exceptions at most; results are free from serious doubts about generalizability, bias, or flaws in research design. Studies with negative results have sufficiently large samples to have adequate statistical power.
II Moderately strong evidence. The evidence is from studies of strong design, but some uncertainty remains because of inconsistencies or concern about generalizability, bias, research design flaws, or adequate sample size. Alternatively, the evidence is consistent but derives from studies of weaker design.
III Weak evidence. The evidence is from a limited number of studies of weaker design. Studies with strong design either have not been done or are inconclusive.
IV No published literature (for those situations in which no study addressed the question).

For the four treatment KQs, we found the strength of the body of evidence to be of mixed quality that varied considerably across the three disorders (Table 37). For KQ 1, evidence for treatment efficacy, we judged the AN literature to be weak (III); the exception was for psychotherapy for adolescents with AN, for which more evidence was available yielding a moderate rating (II). The strongest treatment efficacy literature was for BN; we judged both medication and behavioral interventions as strong (I), although we gave self-help and other interventions only a weak rating (III). For BED, both medication and behavioral interventions were viewed as moderate (II) with self-help and other interventions as weak (III).

Table 37 Strength of evidence concerning four treatment key questions

Interventions | KQ 1 | KQ 2 | KQ 3 | KQ 4
Anorexia Nervosa
Medication and Medication plus Behavioral Interventions
Adults | III | III | III | IV
Adolescents | III | III | III | IV
Behavioral Interventions
Adults | III | IV | III | IV
Adolescents | II | IV | III | IV
Bulimia Nervosa
Medication and Medication plus Behavioral Interventions
All ages | I | I | III | IV
Behavioral Interventions
All ages | I | IV | II | IV
Self-help
All ages | III | IV | III | IV
Other
All ages | III | IV | III | IV
Binge Eating Disorder
Medication and Medication plus Behavioral Interventions
Adult | II | I | III | IV
Behavioral Interventions
Adult | II | IV | III | IV
Self-help
Adult | III | IV | III | IV
Other
Adult | III | IV | III | IV

Regarding harms of therapy (KQ 2), we gave strong ratings (I) to the literature on medication interventions for BN and BED. The evidence for harms of other interventions for all three disorders received ratings of either weak (III) or nonexistent (IV). Behavioral trials rarely reported harms associated with treatment.

KQ 3 dealt with factors associated with or influencing therapeutic outcome. With the exception of behavioral interventions for BN, which we rated moderate (II), we rated the literature for all three disorders as weak (III). Very few well-designed studies addressed those factors that lead to good or poor outcome in clinical trials.

Finally, KQ 4 addressed differences in treatment outcome by age, sex, gender, race, ethnicity, or cultural group. For all three disorders and all types of interventions, we rated the literature as nonexistent (IV). The treatment literature for eating disorders has virtually ignored all these factors.

As reported in Table 38, we found considerable evidence to address factors related to outcomes among individuals with AN and BN (KQ 5) and rated the evidence for both of these disorders as moderate (II). In contrast, the evidence available to address factors related to BED outcomes (KQ 5) was much more limited and, thus, weak (III).

Table 38 Strength of evidence concerning two outcomes key questions

Eating Disorder | KQ 5 | KQ 6
Anorexia nervosa | II | III
Bulimia nervosa | II | IV
Binge eating disorder | III | IV

The AN outcomes literature includes one prospective cohort study (following individuals identified in the community) with a comparison group design and one case series study (following a treatment population) with a comparison group design. The remaining literature follows case series of patients without comparisons. Some studies use strong methodological designs that control for length of followup and the effect of independent predictors. However, results were not consistent across studies.

The BN outcomes literature included no prospective cohort studies but did include several studies with strong methodological designs, including one case series study with a comparison group. However, partially because the literature is inconsistent in the methodology used to measure outcome, few factors were found to be consistently related to outcomes and so uncertainty remains.

The BED literature included only three studies. Much of the data provided in these studies was descriptive and offered very limited information concerning factors related to outcomes.

We used the body of literature that met our inclusion criteria for answering KQ 5 to address KQ 6 concerning differences in outcomes by sex, gender, age, race, ethnicity, or cultural group. We graded the AN literature as weak (III) and the BN and BED literature as nonexistent (IV). The AN literature had limited evidence discussing the effect of age of onset on outcomes, but results were not conclusive. The AN literature yielded no evidence to evaluate differences in outcomes by any other KQ 6 criteria. No study addressed any of these concerns for BN and BED.

Our review supports and extends previous systematic reviews on treatment of eating disorders, including several Cochrane reports. Broadly, Cochrane reviews of AN treatment concur that the literature is weak, made no specific recommendations regarding AN treatment, and encouraged larger well-designed trials.^390^ For psychotherapy for BN and binge eating, a Cochrane review supported cognitive behavioral therapy (CBT) for BN, in individual or group format, and encouraged further study of self-help.^391^ For antidepressant treatment, Cochrane reviewers concluded that single antidepressant agents were clinically effective for BN in comparison to placebo, with greater remission rate but also greater dropouts. No differential effect regarding efficacy and tolerability among the various classes of antidepressants was reported.^392^ Examining combinations of psychotherapy and antidepressants for BN, another Cochrane review reported that combination treatments were superior to psychotherapy alone, that psychotherapy appeared to be more acceptable to participants, and that the addition of antidepressants to psychological treatments decreased the acceptability of the psychological intervention.^393^

In addition, guidelines from the National Institute of Clinical Effectiveness (NICE) in the United Kingdom (http://www.nice.org.uk/) concur that AN evidence is weak. The NICE authors assigned high grades to CBT for BN and BED and to antidepressants for BN. For both BN and BED, NICE recommended self-help as an initial treatment step.

### Managing Patients with Medication Alone

Managing individuals with AN with medication only is inappropriate, based on evidence reviewed here. No pharmacological intervention for AN has a significant impact on weight gain or the psychological features of AN. Although mood may improve with tricyclic antidepressants, this outcome is not associated with improved weight gain. Moreover, medication treatment for AN is associated with high dropout rates, suggesting that the currently available medications are not acceptable to individuals with AN.

For BN, good evidence indicates that fluoxetine (60 mg/day) reduces core bulimic symptoms of binge eating and purging and associated psychological features of the eating disorder in the short term. Based on two studies, the 60 mg dose performs better than lower doses and may contribute to decreased relapse at 1 year; however, patients do not tend to remain on the drug. Preliminary evidence exists for other second-generation antidepressants (trazodone and fluvoxamine), an anticonvulsant (topiramate), and a tricyclic antidepressant (desipramine). Preliminary evidence exists that monoamine oxidase inhibitors (MAOIs) are associated with decreased vomiting in the treatment of BN, although diet should be closely monitored.

Medication trials for BED have focused primarily on overweight individuals with BED. In these individuals, desired outcomes are twofold: weight loss and abstinence from binge eating. The majority of medication research for BED reflects short-term trials. Preliminary efficacy has been shown for selective serotonin reuptake inhibitors (SSRIs), one serotonin, dopamine, and norepinephrine uptake inhibitor, one tricyclic antidepressant, one anticonvulsant, and one appetite suppressant. In the absence of abstinence data and long-term followup, however, we do not know whether observed changes in binge eating, depression, and weight persist.

### Managing Patients with Behavioral Interventions Alone

For adult AN, we have tentative evidence that CBT reduces relapse risk for adults with AN after weight restoration has been accomplished. By contrast, we do not know the extent to which CBT is helpful in the acutely underweight state, as one study found that a manual-based form of nonspecific supportive clinical management was more effective than CBT and interpersonal psychotherapy (IPT) in terms of global outcomes during the acute phase. No replications of these studies exist.

Family therapy as currently practiced has no supportive evidence for adults with AN and a comparatively long duration of illness. Overall, family therapy focusing on parental control of renutrition is efficacious in treating younger patients with AN; these approaches lead to clinically meaningful weight gain and psychological improvement. Although most studies of family therapy compared one variant of family therapy with another, two studies produced results suggesting that family therapy was superior to an individual therapy for adolescent patients with shorter duration of illness.

For BN, evidence for CBT is strong. Although IPT is also as effective, at 1-year followup, based on one study, symptomatic change appears to be more rapid with CBT. This factor decreases the time that patients are exposed to the symptoms of BN. Dialectical behavioral therapy (DBT) and guided imagery both show preliminary promise for BN patients.

For BED, CBT decreases the target symptom of binge eating. It does not, as currently delivered, promote weight loss in overweight patients. DBT may hold promise for BED patients as well.

### Managing Patients with Combination Interventions

Although many of the medication trials for AN were conducted within the context of basic clinical management, no study that systematically studied medication plus psychotherapy for AN met our inclusion criteria.

For BN, the combined drug plus behavioral intervention studies provide only preliminary evidence regarding the optimal combination of medication and psychotherapy or self-help. Although some preliminary evidence exists for incremental efficacy with combined treatment, given the variety of designs used and lack of replication, evidence remains weak.

For BED, the combination of CBT plus medication may improve both binge eating and weight loss outcomes. Sufficient trials have not been done to determine definitively which medications are best at producing and maintaining weight loss in this population. Moreover, the optimal duration of medication treatment for abstinence from binge eating and sustained weight loss has not yet been addressed empirically, yet weight-loss effects of medication are generally known to cease when the medication is discontinued.^394^

### Managing Patients with Novel Interventions

Across the three disorders, we found evidence of various innovative approaches that seem to hold promise, especially for conditions as complex as these eating disorders. Nonetheless, nothing can be said definitively because the trials were small and inconclusive.

### Reducing Mortality

The AN outcomes literature clearly and consistently identified that the risk of death is significantly higher in the AN population than would be expected in the population in general. Life-threatening complications of the disease include not only those directly related to weight loss and other physical problems but also a significantly elevated risk of suicide.

Studies were inconsistent concerning whether deceased patients had been included in the analysis sample at followup. Therefore, factors related to poor outcomes did not always include mortality risk. Several studies identified factors related to death versus all other outcomes. Only by including death with other outcome categories can we determine if factors related to death differ from factors related to other poor outcomes.

Individuals with BN and BED were not identified as being at elevated risk of death.

## Methods and Other Deficiencies in Reviewed Studies and Recommendations to Overcome Them

### Sample Sizes, Attrition, and Statistical Power

Adequate sample sizes. Especially in AN clinical trials, sample size was often insufficient to draw conclusions regarding differential efficacy across groups. Even when investigators did power calculations, they often did not plan an adequate allowance for attrition. Given this limitation, researchers using designs that contrasted one approach with another most commonly observed no differences across interventions. This result was especially true in trials of behavioral interventions and even more so in those that included a large number of comparison groups.

Accurate power analyses should be conducted before starting any study and presented in the methods section. Larger multisite studies should be conducted as a means of bolstering patient numbers.

Subgroup analyses. Even in the face of small sample sizes, many authors conducted subgroup analyses on outcome variables, often in the absence of a priori hypotheses. In these small studies, the ability to discern even large differences between groups is limited, and some findings might arise by chance. Investigators must avail themselves of adequate statistical assistance to ensure against inappropriate analyses of this sort.

Attrition. Loss to followup and dropout from clinical trials is especially problematic in AN studies.^395^ Individuals with AN are often in denial, deeply fearful of weight gain (which is the key treatment outcome), and hesitant to take medication. High attrition compromises the integrity of outcome data; differential attrition between treatment intervention groups and comparison (e.g., usual-care or placebo) groups is even more damaging. In light of high attrition, researchers often reported completer analyses rather than intention-to-treat analyses, and the former practice can bias results.

Substantial attention needs to be paid to enhancing motivation for treatment in individuals with AN and to improving retention in clinical trials. Although dropout is somewhat lower in BN and BED studies than in AN studies, investigators should also address these factors in clinical trials for these disorders.

### Study Design and Statistical Analysis Issues

In general, the eating disorders literature suffers from insufficient rigor with respect to statistical design and analysis in both the planning and conduct of trials. This leads to both gaps and inaccuracies in reporting and interpreting results. Minimally, these problems call into question the validity of the conclusions that can be drawn from individual studies. More broadly, it limits cross-study comparisons and the systematic accumulation of findings that stand the test of time and replication. Ultimately, these problems will hinder the advancement of effective treatments.

Unclear randomization and allocation concealment. Randomization procedures were not of uniformly high standards in the AN, BN, and BED literatures. Many studies failed to report how investigators achieved randomization (if indeed they did achieve it). In many instances, clinical decisions interfered with the integrity of the randomization procedures. No studies reported procedures for allocation concealment.

Trial design challenges. A common problem involves lack of attention to the within-subject repeated design inherent in intervention and treatment trials. For example, studies often indicate the use of repeated-measures analysis but then actually report analysis of posttreatment outcome data only using a paired t-test to identify treatment group differences. In some cases, investigators include baseline data as a covariate (which is not explicitly identical to using a repeated-measures model); in other cases, they do not take baseline data into account at all.

In addition, authors sometimes compute a change (delta) score (posttreatment minus baseline) representing within-subject change over time. This is a reasonable (indeed, often preferable) analytic approach to understand pre-post differences. However, they then fail to account for baseline differences that could result in misinterpretation of mean within-group delta scores; an example is when higher baseline values are associated with smaller delta scores.

Overall, advances in this field demand more clarity in the description of analytical methods employed, including specifically the analytic models that have been determined a priori, and for the use of repeated measures models with appropriate inclusion of covariates. Attention to these recommendations should improve our ability to integrate information from disparate studies and to draw conclusions with higher yield with respect to the design and implementation of future interventions.

Duration of treatment and absence of followup. Only a very few studies included a dimension of differential duration of treatment in their designs. Assuming that a medication trial that lasts weeks is likely to have long-lasting effects on symptoms that have been present often for many years is unrealistic. Realistic duration of treatment and longer followup of patients in clinical trials for AN, BN, and BED are essential. In addition, strategies to develop continuation and maintenance treatments have not yet been addressed in this field. They are a critical next step in both medication and psychotherapy research.

Excessive diagnostic and outcome measures. The field of eating disorders has spawned an unusually large array of diagnostic and outcome assessment measures. The lack of consistency of measures renders comparisons across studies virtually impossible. This problem is an especially important barrier to standardizing measures of weight and weight change in outcome assessments and trials involving AN therapies, especially when age and sex corrections for body mass index (BMI) should be employed. Future efforts to refine and consolidate the number of measures would be a valuable contribution to the field.

Researchers should be careful not to include too many outcome measures in their designs. They need to avoid having many outcome variables at the expense of the most important behavioral indicators. Excessive numbers of outcome measures, especially those that may be closely related, lead to a higher likelihood of Type I errors and an inevitable focus on the minor significant findings that do emerge. This is especially detrimental to understanding the efficacy of therapeutic regimens when those findings are not the most clinically relevant dimensions or when their relevance to recovery is unknown.

Treatment of medical morbidities. Insufficient attention has been paid to addressing the optimal approach to treatment of serious long-term physical sequelae of AN and BN, most notably osteoporosis. We advise that measures of physical health issues be considered in the design of future trials.

Sociocultural context. Although the facilitating nature of sociocultural forces such as emphasis on thinness and unhealthy dieting have long been acknowledged, few treatment or outcome studies have attempted to measure the impact of these pernicious contextual factors. Although these variables are less tractable (for study design and conduct) than more readily measured factors such as eating-disordered behaviors, depression, anxiety, or biomarkers, greater attention to developing effective methods to measure these contextual factors may reveal important and often overlooked factors that influence recovery. This in turn may open new avenues for prevention, community education, policy, and strategies for maintenance of treatment gains.

### Reporting Issues

Lack of definition of stage of illness, remission, recovery, and relapse. For AN, BN, and BED, investigators did not apply consensus definitions of stage of illness, remission, recovery, and relapse. Developing standardized definitions of these terms for each disorder and the means to evaluate them are high priorities for future research. Accomplishing this will require a concerted and orchestrated effort to bring researchers together to develop such definitions and reporting guidelines.

Reporting change as reduction in behaviors rather than abstinence or remission. Especially in the BN and BED literature, researchers commonly reported outcomes such as percentage reduction in binge days, percentage reduction in binges, or amount of time spent binge eating. Although these are potential indicators of therapeutic change, when used alone they can be misleading because individuals with high weekly binge eating can reduce this behavior by even as much as 50 percent but still be highly symptomatic. Depending on the disorder and core behaviors being targeted, future studies should report either abstinence from binge eating, vomiting, and other compensatory behaviors or absence of binge days for a specified duration of time (at least 1 month but preferably longer).

Statistical reporting. Frequently, authors do not report degrees of freedom, making it impossible to decipher the exact nature of the model being tested. Incomplete reporting of results derived from multivariate models is problematic. Authors should take care to report clearly any interaction, between-group, and within-group effects when they employ repeated designs.

Statistically significant differences versus clinically meaningful differences. Across all three disorders attention to distinguishing between statistically significant and clinically meaningful differences is insufficient. For example, significant differences in weight gain in AN and in weight loss in BED may be observed; however, the extent to which group differences as small as 1 kg to 2 kg truly represent clinically meaningful differences is rarely addressed. Definitions of what constitutes clinically meaningful differences in eating disorders are required.

This issue is even more complex when dealing with psychological features of the eating disorder or associated anxiety or depression. Although significant group differences may emerge in a parameter such as hunger, the extent to which this type of finding reflects improvement in the disorder and is a harbinger for remission remains unknown.

## Future Research Needs

### Gaps in the Literature for Interventions

Gaps in the literature can be identified for the specific diseases and for broader issues of research across eating disorders. We first examine deficits in the evidence base for the main types of interventions (for one, two, or all three of the conditions), drawing on the points made above about the quality of articles or strength of evidence. We then turn to broader methods and related issues for the entire body of investigations in these conditions.

Medications. Discovering new medications that target the core biological and psychological features of AN, address adverse medical sequelae such as osteoporosis, and enhance motivation and retention in medication trials are critically needed steps. As noted, fluoxetine offers some benefits for BN patients. Additional studies are required to determine the long-term effectiveness of relatively brief medication trials, the optimal duration of medication treatment, and the optimal strategy for maintenance of treatment gains. In addition, work to identify and test novel medications that decrease the urge to purge (e.g., with antiemetics) or reduce the extent to which binge eating and purging are experienced as reinforcing is also warranted. Medication trials should focus on achieving abstinence from binge eating and purging, not merely reducing the frequency with which these behaviors occur. Efforts to improve retention in medication trials for BN are also warranted, as are additional studies combining medications and behavioral interventions.

For BED medication questions, future investigations should take care to report specifically and separately on two outcomes - weight loss and abstinence from binge eating - because weight loss is less applicable to individuals with BED who are of normal weight. Future BED studies should clearly distinguish between normal weight and overweight participants and address whether treatment goals include both cessation of binge eating and weight loss. The impact of high placebo response should be considered in future trials and designs modified accordingly (e.g., sufficiently long placebo run-in phases).

Across all three disorders, no effort has been made to study drug augmentation effects. All trials were monotherapy trials; only a few allowed sequential medication in nonresponders. Investigators should consider augmentation strategies in their future studies.

Behavioral interventions. Strategies for enhancing CBT to change both binge eating and weight loss should be included in the next generation of behavioral studies. They should also focus on strategies for enhancing efficacy of CBT and how best to treat CBT nonresponders. On the basis of preliminary trials, DBT also deserves further study.

Combination interventions. The absence of trials combining medications and behavioral interventions (e.g., psychotherapy) is a serious deficit in the AN literature, and it is striking given that treatment delivered in the community for AN patients is often some form of combination treatment. Future studies must address the efficacy of various combinations of treatments for individuals with AN. Future studies should further explore optimal combinations and how best to combine treatments for BN patients who do not respond to CBT or fluoxetine alone. For BED patients, the needed research centers more on which medications have the greatest efficacy for producing desired outcomes and the optimal duration of medication use.

Novel and “borrowed” interventions. Research on innovative medications and behavioral treatments are warranted, especially given the state of treatment of AN. Medications studied to date have either focused on peripheral symptoms such as depression or anxiety or attempted to capitalize on medication side effects such as weight gain, with the aim of aiding weight restoration in AN. Of special importance will be trials of novel medications that target core biological and cognitive features of the disorders and that are also acceptable to patients.

Similarly, psychotherapies applied to eating disorders have been borrowed from other fields such as depression (CBT and IPT), anxiety disorders (exposure with response prevention), and personality disorders (DBT). We should actively seek to further adapt psychotherapeutic interventions that are tailored to the unique core pathology of eating disorders (e.g., drive for thinness, body dissatisfaction, appetite dysregulation) and that are both efficacious and acceptable to the patients. New behavioral interventions that target motivation to change and encourage retention in treatment are required. Further dismantling of complex therapies such as CBT to determine the active therapeutic components is also warranted.

Other fields are benefiting from the application of new information technologies to the treatment of illness. Adequately powered clinical trials that include the use of email, the Internet, personal digital assistants, text messaging, and other technological advances to enhance treatment will add to future treatment development. These approaches may be well suited to disorders marked by shame, denial, and interpersonal deficits and where availability of specialty care is limited.

Multidisciplinary interventions. Specialist inpatient and partial hospitalization treatment of AN often reflects a multidisciplinary approach: medicine, psychiatry, psychology, nutrition, family therapy, and sometimes additional disciplines such as recreational therapy and occupational therapy. The majority of treatment trials have been monotherapeutic. When they are multidisciplinary, the actual component of multidisciplinarity was rarely a variable on which patients were randomized. Studies that directly address the therapeutic benefits of and optimal approach to multidisciplinary treatment are required.

Maintenance of gains after drug discontinuation. For all three disorders, investigators typically failed to provide adequate follow-up time for medication trials. This means they cannot determine the extent to which positive behavior changes seen during medication administration are maintained over time. At minimum, such studies should have at least 1 year of followup. Especially with BN and BED, for which evidence for the short-term efficacy of medication interventions exists, additional information on maintenance of treatment gains, prevention of relapse, and optimal duration of medication treatment are critical next phases for clinical trials.

### Gaps in the Literature for Certain Types of Patients

Patients with anorexia nervosa. AN is a serious psychiatric illness. Treatment research on AN is particularly challenging given the characteristic denial of illness, high drop-out rates from treatment, and the limited population prevalence in any single catchment area. Despite the fact that this is the most challenging eating disorder to treat, our evidence base is scant. Studies tend to be small, inadequately powered, and hence inconclusive. Medications studied to date have either focused on peripheral symptoms such as depression or anxiety or attempted to capitalize on medication side effects such as weight gain, with the aim of aiding weight restoration in AN. Both medication and behavioral intervention trials tend to be derivative—using medications or behavioral interventions that are borrowed from other areas of medicine without focusing on the core symptoms of AN.

We noted above some specific gaps related to medication and psychotherapy interventions. We reiterate here the urgency of more, and better, research on this disease. Trials of novel medications that target the core cognitive symptoms and biological processes of AN and medical sequelae are especially needed to move the field forward.

The literature on AN has failed to distinguish sufficiently between interventions targeted at individuals before or after weight restoration and has failed to address the optimal approach to renutrition. Indeed, whether medication and behavioral interventions have different outcomes depending on weight status remains murky. Given that low weight and malnutrition can interfere with the efficacy of medication and the ability to process information in psychotherapy, the optimal timing of the administration of medications and therapy vis-a-vis weight restoration is a critical question that remains unaddressed.

Patients with eating disorders not otherwise specified (EDNOS). Several treatment centers have reported that the majority of individuals who seek treatment for an eating disorder receive a diagnosis of EDNOS.^88,^ ^89^ EDNOS is a compound category illustrated in the Diagnostic and Statistical Manual, Version IV (DSM IV), by six examples including BED. Despite the patient characteristics that lead to this diagnosis, investigators appear to have ignored systematically those with EDNOS diagnoses. Given the preponderance of individuals with EDNOS diagnoses in treatment settings, this is a serious shortcoming of the literature.

In part, this gap reflects the greater clarity and homogeneity that investigators can achieve in clinical trials when they recruit only individuals with clearly defined AN or BN. However, the price of this clarity is generalizability and, ultimately, understanding the effectiveness of interventions tested. Although some trials have begun to expand inclusion criteria to reflect typical clinical practice, others have retained strict inclusion criteria. Only by further clarifying clinical syndromes within the current EDNOS category and investigating the optimal approach to treat these conditions will we be able to determine how best to treat the majority of treatment-seeking individuals.

Improved epidemiologic data are required to determine whether the frequency with which EDNOS is seen in the clinic reflects population prevalence rates of the various eating disorders. In addition, active strides should be taken to characterize the syndromes that are captured under the heading of EDNOS and to determine the best way to treat conditions that exist under that umbrella diagnostic category.

The need for additional attention to individuals with EDNOS was clearly shown through our review of the outcomes literature. EDNOS is a common outcome among individuals who formerly had AN or BN. However, virtually nothing is known about the persistence of these conditions.

Age and lifespan orientation. The treatment literatures on AN, BN, and BED differ in how they examine differential therapeutic outcomes by age group. For all three disorders, a more thoughtful lifespan approach is required to determine optimal approaches from childhood through older adulthood.

The AN literature is devoid of medication studies for adolescents; drug trials have focused exclusively on adults. Future medication trials should explore medication efficacy in adolescents and the differential efficacy of medications between adolescents and adults.

In contrast, behavioral interventions have focused more on adolescent patients, possibly because of the existence of various family therapy models that are well suited to the context within which adolescent AN arises. Nonetheless, behavioral interventions should pay greater attention to the appropriateness of various approaches across the lifespan (including duration of illness) and of adaptations that depend on age of the patient.

The extent to which CBT approaches to adolescent treatment of AN were adapted to match the developmental level of the patients is unknown. Likewise, approaches that are effective in adolescents may be inappropriate for adults, although developmentally appropriate adaptations may be worthy of study. For example, the relative efficacy of family therapy for adolescents with AN may signal the important role of the family. However, the family of relevance for an adult with AN may be her or his spouse and children rather than family of origin. Such permutations of the therapeutic approach have not yet been tested.

For BN, most commonly older adolescent and adult patients received the same treatment and researchers made no effort to explore differential outcome by age group. Future studies that delve more into mechanisms of treatment response should take care to explore differential age effects.

For BED, no medication or behavioral intervention trials exist for adolescents. No study enrolled patients younger than 18; many included individuals up to 65 without documenting age effects. The first step for BED research is to acquire epidemiologic data to determine the extent to which this disorder is a problem for adolescents. The second needed step is to explore differential outcomes by age.

Males and females. Although males suffer from eating disorders, they are underrepresented in clinical trials of AN and BN. When included, their numbers are usually too small to be analyzed separately. Clinical trials of BED often include a greater number of men; however, no study has reported on differential efficacy by sex.

This situation can be remedied, first, by better studies comparing the phenomenology of AN, BN, and BED in males and females. Second, more extensive epidemiological data can provide more accurate estimates of the actual sex ratio in the population. Third, efforts should be expanded to explore differential treatment needs and outcomes in males and females across the age spectrum. Fourth, we have no data on whether treatment for eating disorders is best conducted in mixed-sex or single-sex environments. Fifth, multisite trials can be designed to increase sample size of male participants.

We note that much of the literature to date deals with males and females (a construct related to sex and biology). Very little research, apparently, tries to deal with gender (a construct related to socialization and social roles). We believe that more attention to the difference between these ideas, and some effort to understand the impact of gender, and not simply sex, may be valuable in understanding treatment approaches and efficacy.

Race and ethnicity. The majority of the literature on AN fails even to report the race and ethnicity of participants. All descriptions of participants should include this critical parameter. Although the more recent BN and BED literature has improved on this point, no studies of medication or behavioral interventions have addressed the issue of whether treatment efficacy differs by race or ethnic background. This is a serious omission in the literature.

To remedy this shortcoming, we must collect adequate epidemiologic data to provide critically needed information about the frequency with which eating disorders occur across racial and ethnic groups. Such data would provide guidance for planning targeted recruitment in clinical trials and enable researchers to set priorities for approaches to incorporating race and ethnicity into both treatment and outcomes studies. In addition, further exploration of sociocultural factors (e.g., stigma) may also assist with understanding both underdetection and underrepresentation of racial and ethnic minorities in research studies.

Underserved populations. The literature on AN, BN, and BED is devoid of any mention of specific issues of gay, lesbian, transsexual, or transgender individuals. These parameters should be systematically recorded in both treatment and outcome studies.

### Gaps in the Overall Evidence Base

The United States' contribution to the literature. The literatures on AN, BN, and BED are geographically imbalanced. Although the United States has contributed considerably to the literature on BN and BED, it has done much less on both the treatment and outcome literature for AN. Although outcome studies of AN may be more difficult in the United States because of the mobility of the population, large-scale multisite treatment trials are perhaps more feasible in the United States given the number of academic treatment centers, the generally shared language, and the size of the population base. The United States should expand its contribution to the global literature for the next phase of treatment studies, especially for AN.

In addition, the unique racial and ethnic composition of the United States could assist with addressing the vacuum of information regarding differential treatment outcome by race and ethnicity across AN, BN, and BED. For the outcomes literature, the majority of literature for AN comes from outside of the United States. The extent to which data from outside the United States accurately reflect outcomes in the United States is unclear.

Replication. The hallmark of good science is replication. One major weakness of the existing literature and a critical need for the future is replication. Once efficacious interventions are identified, adequately powered replication studies should be supported to confirm their effectiveness. Results of such studies would need to be careful to report findings using measures and statistical techniques that would allow for direct comparisons across trials.

Large multisite randomized controlled trials. The majority of eating disorders treatment studies are small, single-site trials. The average sample size of AN trials, 23, illustrates this point robustly. Future multisite trials will facilitate patient recruitment, enhance statistical power, enable meaningful subset analyses, buffer against high drop-out rates, and improve generalizability of results. Working in partnership with insurance companies to enable such trials in the current reimbursement milieu may be critical to success.

Generalizability and key treatment questions in the community. Clinical trials for AN in particular do not adequately reflect the type of treatment typically delivered in the community. Nor do clinical trials for AN address some of the key challenges facing clinicians who treat this disorder in inpatient and partial hospitalization or residential settings.

For low-weight patients with AN, the first treatment challenge is weight restoration. Guidelines from the American Psychiatric Association (APA) suggest that individuals at 75 percent of ideal body weight (IBW) or lower are candidates for inpatient weight restoration, although many other factors influence level of care decisions. When facilities are available, weight restoration occurs in hospital, followed by various levels of step-down marked by increasing autonomy and exposure to real-life eating and emotional situations.

No clinical trials for AN address the optimal approach to inpatient weight restoration that can achieve the most lasting gain. This also includes nutritional trials of optimal approaches to renutrition. No studies address the accuracy of the recommendation for hospitalization at 75 percent IBW. No studies address the optimal conditions under which a patient should be discharged from inpatient treatment and stepped down to less structured environments. Given the financial expense of prolonged inpatient hospitalizations and the toll on both patient and family, the conditions under which extended hospitalizations are superior to intensive outpatient management should be the focus of future studies.

Harms of treatment. Trials of medication or behavioral interventions for patients with AN, BN, and BED do not routinely describe the degree of medical compromise or strategies to monitor for potential harm in malnourished patients. Indeed, behavioral intervention trials often completely overlook the fact that their interventions may have adverse effects on patients. Especially given the high drop-out rates from AN trials, behavioral interventions should pay greater attention to both physical and psychological harms associated with interventions. All studies should report adverse events associated with interventions with these disorders. In addition, with AN, researchers should determine, especially within medication trials, whether adverse events differ between the underweight and the weight-restored state.

### Issues in Outcomes Research

Outcomes research and treatment research. One serious gap in the evidence base about eating disorders is the absence of “cross talk” between the outcomes and the treatment literatures. Outcomes literature reveals intriguing problems that persist years after the onset of AN. One example is the presence of autism spectrum disorders reported in the Göteborg cohort.^344^–^346,^ ^349,^ ^356^ Such observations could provide critical information to individuals designing new interventions for AN. Targeting social information processing deficits, for example, could be one way to enhance AN treatment delivery. Paying greater attention to premorbid traits and traits that persist after recovery or through persistent illness may help to enhance treatment efficacy by identifying new treatment targets.

In addition, greater attention to demographic patterns in outcome studies such as typical age of recovery from AN may assist with better appraising where an individual entering treatment is in the course of her or his illness. This could assist with enhancing engagement in treatment and reducing the number of dropouts.

Prospective cohort studies and comparison groups. Virtually all the outcome results and relationships that we identified came from case series studies. This design limits generalizability beyond the specific treatment population being studied. Only one prospective cohort study has been conducted with individuals identified with AN; none has been done among persons with either BN or BED. Therefore, little evidence exists as to whether outcomes differ across treatment populations, individuals in the general population who suffer from these disorders, and those who may not meet threshold diagnostic criteria yet report symptoms or features of the disorders.

Of particular interest would be studies that address factors associated with successful outcomes in AN or BN; these should explore trajectories of recovery and how current diagnostic nosology captures those trajectories. For example, an individual with AN who is assessed 5 years after the onset of that illness may be given a diagnosis of EDNOS; this pattern fails to acknowledge that the patient is on a recovery trajectory from AN. The appropriateness of receiving a diagnostic label (EDNOS) different from the original diagnosis (AN), rather than a specific indicator such as AN in partial remission, has yet to be addressed adequately in the literature.

Tracing outcomes across diagnoses. Many individuals who at one time suffered from AN or BN continue to experience less severe eating disorders in later years. Use of dichotomous or simplistic measures of disease state is increasingly seen as uninformative. Additional research is needed that can sufficiently capture the factors associated with transitions in severity of eating disorder diagnoses.

Statistical methods for outcomes research. Outcomes studies vary in their statistical sophistication. At their best, studies used multivariate techniques to control for the influence of various independent variables on outcomes; they may also employ survival analyses techniques to control for differences in the length of time that patients were followed. At their more rudimentary state, many studies simply presented descriptive comparisons between a series of prognostic factors and outcomes of interest, or they employed techniques more appropriate for exploratory research (e.g., stepwise regression). We encourage investigators doing outcomes research (as contrasted with trials) to plan from the outset on using advanced statistical and analytic methodological approaches.

Impact of weight loss treatment on binge eating. Although not a focus of this review, with the ever-increasing obesity epidemic,^396,^ ^397^ an important area of study will be the impact of various weight loss treatments on binge eating and on the development of eating disorders and eating-disordered behaviors. Programs developed for obesity prevention and treatment in both children and adults should be carefully monitored to ensure that no untoward effects emerge that increase eating-disordered behaviors.^398^–^401^

Cost-effectiveness analyses. Only rarely has the cost-effectiveness of interventions for AN, BN, and BED been addressed. At some point, however, some medications, behavioral approaches, or combination therapies will appear to be efficacious in trials or effective in broader trials or observational studies. Then, clinicians, insurers, health plan administrators, and others will want information on the relative cost-effectiveness of different therapeutic options. To provide information to address these questions, future studies should include data collection of costs and cost-effectiveness analyses in their designs.

## Conclusions

The literature regarding treatment efficacy and outcomes for AN, BN, and BED is of highly variable quality. For AN, the literature on medications was sparse and inconclusive. No studies combining medication with behavioral interventions met inclusion criteria. Evidence suggests that specific forms of family therapy are efficacious in treating adolescents, and preliminary evidence suggests that CBT may reduce relapse risk for adults after weight restoration and that a manual-based form of nonspecific supportive clinical management may be effective in underweight adults.

For BN, fluoxetine (60 mg/day) decreases the core bulimic symptoms of binge eating and purging and associated psychological features in the short term. CBT administered individually or in groups reduced core behavioral symptoms and psychological features in both the short and long term. How best to treat individuals who do not respond to CBT or fluoxetine remains unknown.

In BED, CBT reduced binge eating and leads to greater rates of abstinence when administered either individually or in group format, persisting for up to 4 months after treatment; however, CBT does not lead to weight loss in individuals with BED. Medications may also play a role in the treatment of BED although further research addressing how best to achieve both abstinence from binge eating and weight loss in overweight patients is required.

Higher levels of depression and compulsivity were associated with poorer outcomes in AN; increased mortality was associated with concurrent alcohol and substance use disorders. Only depression was consistently associated with poorer outcomes in BN; BN was not associated with an increased risk of mortality. Because of sparse data, we could reach no conclusions concerning BED outcomes. We uncovered weak to no evidence to address sociodemographic differences in either treatment or outcomes for any of these disorders.

The quality of the literature about treatment efficacy and outcome for AN, BN, and BED is highly variable. In the treatment literature, the largest deficiency rests with treatment efficacy for AN; we rated this literature as the weakest.

Future AN studies require large numbers of participants, multiple sites, clear delineation of the age of participants, and interventions that are tailored to the unique core pathology and medical sequelae of the illness. For BN, future studies should address novel treatments for the disorder, optimal duration of intervention, and optimal approaches for those who do not respond to medication or CBT. For BED, future studies require better explication of how best to target both binge eating and weight loss goals, optimal duration of intervention, and prevention of relapse.

For all three disorders, exploring additional treatment approaches is warranted. In addition, research teams should pay greater attention to factors influencing outcome, harms associated with treatment, and differential efficacy by age, sex, gender, race, ethnicity, and cultural group. Consensus definitions of remission, recovery, and relapse are essential. For both treatment and outcome literature, greater attention is required to the presentations currently grouped under the heading of EDNOS.

Outcome studies, especially for BN and BED, should emphasize population-based cohort studies with comparison groups and plan for adequate durations of follow-up. Ongoing psychiatric epidemiology studies should routinely include assessments of eating disorders. Epidemiologic studies of BMI and obesity trends should include assessments of eating-disordered behavior. Population-based studies should include measures of disability and impairment associated with eating disorders. For both future treatment and outcome studies, researchers must carefully attend to issues of statistical power, research design, and sophistication and appropriateness of statistical analyses.