# Outcomes of Eating Disorders

This chapter presents the results of our literature search and findings for key questions (KQs) 5 and 6. KQ 5 asks what factors are associated with outcomes among individuals with the following eating disorders: anorexia nervosa (AN), bulimia nervosa (BN), and binge eating disorder (BED). KQ 6 asks whether outcomes for each of these disorders differ by sex, gender, age, race, ethnicity, or cultural groups.

We report our results separately for each disease in three main sections of this chapter. Use of the term “significant” means that differences over time or between groups were statistically significant at least at the P < 0.05 level.

We include literature that discusses more than one disease if findings do not combine individuals with different eating disorders. The review focuses on four main outcomes categories of interest: those related to eating, those involving psychiatric or psychological variables, those measured by biomarkers (e.g., weight, menstruation), and death. Many studies were conducted outside the United States, including Germany, England, Scotland, Sweden, China, Japan, New Zealand, and Australia. For that reason, we note in many cases below the setting (city, country) of the studies to emphasize the extent to which this literature is not directly generalizable to US populations and reflects variations across locales.

We include summary tables containing information on outcomes for studies that we rated fair or good. Similar to text, tables group studies by design: cohort (following a group of individuals, with the disease, identified from the community) or case series (following a group of individuals, with the disease, who received treatment) and whether a nondisease comparison group is followed as well. Articles that discuss results from the same study (the same sample for the same amount of time) are grouped in the same row. Finally, within these categories, we list studies alphabetically by author.

Six of the 62 outcomes articles we identified presenting outcomes for individuals with AN, BN, or BED received a quality rating of “poor;” Table 28 documents the reasons why these studies received this rating. Although each study was not deficient in all areas, common concerns contributing to a low rating included the following: a study involved only participants from one eating disorder program in one location or lacked a description of the location; the study did not have a comparison group; the statistical analysis did not include a power analysis or the authors did not report that they conducted any power analyses; the statistical analysis did not have necessary controls for confounding; and outcome assessors were not blinded to study group or blinding status was not described. As in earlier chapters, we do not discuss these studies further in the text.

Table 28 Outcome studies: reasons for poor quality ratings and number of poor ratings by disease type

Reasons Contributing to Poor Ratings | Types of Disease, Number of Times Flaw Was Detected, and Citations
Research Aim
Hypothesis not clearly described | Anorexia Nervosa: 0
| Bulimia Nervosa: 0
| Binge Eating Disorder: 0
Study Population
Characteristics not clearly described | Anorexia Nervosa: 1^331^
| Bulimia Nervosa: 0
| Binge Eating Disorder: 0
No specific inclusion or exclusion criteria | Anorexia Nervosa: 2^331,332^
| Bulimia Nervosa: 1^333^
| Binge Eating Disorder: 0
Study groups not comparable to each other and/or to non-participants with regard to confounding factors or characteristics | Anorexia Nervosa: 0
| Bulimia Nervosa: 0
| Binge Eating Disorder: 0
Eating Disorder Diagnosis Method
Used independent clinician diagnosis or method used not reported | Anorexia Nervosa: 2^331,334^
| Bulimia Nervosa: 0
| Binge Eating Disorder: 0
None used to diagnose patients similar in treatment/disease and comparison groups | Anorexia Nervosa: 0
| Bulimia Nervosa: 0
| Binge Eating Disorder: 0
Study Design
Participants drawn from a treatment program in one city or area not reported | Anorexia Nervosa: 5^332,334^–^337^
| Bulimia Nervosa: 1^333^
| Binge Eating Disorder: 0
No comparison group | Anorexia Nervosa: 6^332^,^331,334^–^337^
| Bulimia Nervosa: 1^333^
| Binge Eating Disorder: 0
Statistical Analysis
Statistics inappropriate | Anorexia Nervosa: 0
| Bulimia Nervosa: 0
| Binge Eating Disorder: 0
No controls for confounding (if needed) | Anorexia Nervosa: 4^331,^,^332,^,^335,336^
| Bulimia Nervosa: 0
| Binge Eating Disorder: 0
Power analysis not done or not reported | Anorexia Nervosa: 5^331,^,^332,334^–^336^
| Bulimia Nervosa: 1^333^
| Binge Eating Disorder: 0
Results/Outcome Measurement
Outcome assessor not blinded or not reported | Anorexia Nervosa: 3^331,^,^332,337^
| Bulimia Nervosa: 0
| Binge Eating Disorder: 0
Outcome measures not standard, reliable, or valid in all groups | Anorexia Nervosa: 0
| Bulimia Nervosa: 0
| Binge Eating Disorder: 0
Interpretation of statistical tests inappropriate | Anorexia Nervosa: 0
| Bulimia Nervosa: 0
| Binge Eating Disorder: 0
External Validity
Population not representative of US population relevant to these treatments | Anorexia Nervosa: 2^331,336^
| Bulimia Nervosa: 0
| Binge Eating Disorder: 0
Discussion
Results do not support conclusions, taking possible biases and limitations into account | Anorexia Nervosa: 0
| Bulimia Nervosa: 0
| Binge Eating Disorder: 0
Results not discussed within context of prior research | Anorexia Nervosa: 0
| Bulimia Nervosa: 0
| Binge Eating Disorder: 0

For each included study, detailed evidence tables appear in Appendix C.^‡‡^ Evidence Table 15 contains the included articles for AN outcomes; Evidence Table 16, articles for BN outcomes; and Evidence Table 17, articles for BED outcomes. Within each table, studies are listed alphabetically. Studies with outcomes for individuals with both AN and BN are in evidence tables for both diseases. To answer KQ 6, we used the literature that met our inclusion criteria and was relevant to answer KQ 5.

‡‡ Appendixes cited in this report are provided electronically athttp://www.ahrq.gov/downloads/pub/evidence/pdf/eatingdisorders/eatdis.pdf.

## Anorexia Nervosa

Our discussion of AN outcomes includes 38 articles exclusively discussing individuals with AN^3,^ ^7,^ ^177,^ ^331,^ ^332,^ ^334^–^366^ and seven articles discussing individuals with both AN and BN.^367^–^373^ First we discuss results for KQ 5, then KQ 6.

### Key Question 5: Factors Associated with Outcomes

Eating-related outcomes. Table 29 presents outcomes from studies rated fair or good; we discuss factors associated with outcomes in the text. Types of studies include prospective cohort with a nondisease comparison group and case series with and without a nondisease comparison group.

Table 29 Eating-related outcomes: anorexia nervosa

Authors, Year | Country
(Quality Score) | Sample Size | Outcomes
Prospective Cohort, Comparison Group
Gillberg et al., 1994^345^ | Sweden | Years followed (mean): 5
(Good)
Råstam et al., 1995^356^ | Cases: 51 | ED dx at FU: AN: 6%; BN: 22%; EDNOS: 14%; None: 59%
(Good) | Comparisons: 51 | Recovered (M-R scale): 47%
| | M-R outcomes: Good: 41%; Intermediate: 35%; Poor: 24%
Nilsson et al., 1999^362^ | Sweden | Years followed (mean): 10
(Good)
Råstam et al., 2003^349^ | Cases: 51 | ED dx at FU: AN: 6%; BN: 4%; EDNOS: 18%; Any ED: 27%
(Good) | Comparisons: 51 | M-R outcomes: Good: 49%; Intermediate: 41%; Poor: 10%
Wentz et al., 2001^352^
(Good)
Case Series, Comparison Groups
Bulik et al., 2000^342^ | New Zealand | Years followed (mean): 12
(Good)
Sullivan et al., 1998^350^ | Cases: 70 | Recovery outcomes: Fully: 30%, Partially: 49%, Chronically ill (current AN, BN or EDNOS): 21%, AN only: 10%
(Good) | Comparisons: 98
Halmi et al., 1991^7^ | USA | Years followed (mean): 10
(Fair) | Cases: 62 | ED dx at FU: AN: 3%, BN: 3%, Normal weight bulimia: 23%, EDNOS: 39%, No ED: 27%, Unknown: 5%
| Comparisons: 62
Case Series, No Comparison Groups
Ben-Tovim et al., 2001^367^ | Australia | Years followed (mean): 5
(Good) | Cases: 92 | ED dx at FU: AN: 21%, BN: 5%, EDNOS: 9%, No ED: 59%, Unknown: 2%, Deceased: 3%
| | M-R-H Outcomes: Good: 34%, Intermediate: 54%, Poor: 13%
Dancyger et al., 1997^353^ | USA | Years followed (mean): 10
(Fair) | Cases: 52 | Recovered: 31%, Good: 13%, Intermediate: 21%, Poor: 35%
Deter et al., 1994^343^ | Germany | Years followed, mean (range): 11.8 (9–19)
(Fair) | Cases: 75 | Good: 54%; Intermediate: 25% Poor:11%, Deceased: 11%
| | AN: 17%
Eckert et al., 1995^338^ | USA | Years followed, mean (range): 9.6 (8.5 – 10.5)
(Fair) | Cases: 76 | Recovered: 24%, Good: 26%, Intermediate: 32%, Poor: 12%, Deceased: 7%
| | ED dx at FU: No ED: 24%, EDNOS: 36%, BN: 22%, AN: 9%, AN/BN: 3%
Eddy et al., 2002 | USA | Years followed, median (range): 8 (8–12)
(Fair) | Cases: 136 | Full recovery (by subtype): Restricting pure: 46%, Restricting not pure: 22%, Binge/purge:39%
| | Relapse from full recovery (by subtype): Restricting pure: 31%, Restricting not pure: 47%, Binge/purge: 68%
| | Restricting subtype crossover to binge/purge subtype: 52%
Fichter et al., 1999^339^ | Germany | Years followed (mean): 6.2
(Good) | Cases: 95 | M-R outcomes: Good: 27%, Intermediate: 25%, Poor: 42% Deceased: 6%
| | ED dx at FU: AN: 27%, BN: 17%, EDNOS: 2%, No ED: 55%
Halvorsen et al., 2004^366^ | Norway | Year followed, mean (range): 8.8 (3.5 – 14.5)
(Fair) | Cases: 51 | M-R outcomes: Good: 80%, Intermediate: 16%, Poor: 4%
| | No ED: 82%, AN: 2%, BN: 2%, EDNOS: 14%
Herzog et al., 1996^370^ | USA | Years followed (mean): 4
(Good) | Cases: 76 | Full recovery (no symptoms for ≥ 8 wks): ANR: 8%; ANBP: 17%
| | Partial recovery (symptom reduction): ANR: 54%; ANBP: 81%
Herzog, Schellberg et al., 1997^359^ | Germany | Years followed, mean: 11.7
(Fair) | Cases:69 | Average time to first recovery: 5.8 years
Herzog et al., 1999^369^ | USA | Years followed: Up to 11 (median = 7.5)
(Good) | Cases: 136 | Full recovery (no symptoms for ≥ 8 wks): ANR: 34%; ANBP: 32% Partial recovery (symptom reduction): ANR: 83%; ANBP: 82%
| | No remission: ANR: 17%; ANBP: 18%
| | Relapse after full recovery: 40%
Isager et al., 1985^340^ | Denmark | Years followed, mean (range): 12.5 (4 – 22)
(Fair) | Cases: 142 | Average annual hazard rate of relapse: 3%
Lee et al., 2003^347^ | Hong Kong | Years followed: 9
(Fair)
Lee et al., 2005^363^ | Cases: 74 | M-R scale outcomes: Good: 62% (typical: 52.6%; atypical: 89.47%), Intermediate: 33% (typical: 42.11%; atypical: 5.26%), Poor: 5% (typical: 5.26%, atypical: 5.26%)
(Fair) | | ED dx at FU: No ED: 46% (typical: 40.68%; atypical: 57.14%), AN: 15%, BN: 20% (typical: 25.42%; atypical: 4.76%), EDNOS: 19% (typical: 15.25%; atypical: 28.57%)
Löwe et al., 2001^348^ | Germany | Years followed (mean): 21.3
(Fair) | Cases: 63 | Full recovery: 51%, Partial recovery: 21%, Poor (including death): 26%, Unknown: 2%
Morgan et al., 1983^355^ | United Kingdom | Years followed, mean (range): 5.8 (4 – 8.5)
(Fair) | Cases: 78 | M-R Outcomes: Good: 58%, Intermediate: 19%, Poor: 19%, Deceased: 1%, unknown: 3%
Strober et al., 1997^341^ | USA | Years followed (range): 10 – 15
(Fair) | Cases: 93 | Full recovery: 76%, Partial recovery: 86%
| | Dx of chronically ill at FU: AN restricting: 3%, AN binge eating: 1%, BN: 10%
Tanaka et al., 2001^351^ | Japan | Years followed, mean (range): 8.3 (4.0 – 17.7)
(Fair) | Cases: 61 | M-R outcomes: Good: 51%, Intermediate: 13%, Poor: 25%,
| | Deceased: 11%

AN, anorexia nervosa; ANBP, anorexia nervosa binge eating and/or purging subtype; ANR, anorexia nervosa restricting subtype; BED, binge eating disorder; BN,bulimia nervosa; Dx, diagnosis; ED, eating disorder; EDE, Eating Disorder Examination; EDI, Eating Disorder Inventory; EDNOS, eating disorder-not otherwise specified; FU, followup; M-R scores: Morgan and Russell Scale; M-R-H Scale, Morgan-Russell-Hayward Scale; SIAB, Structured Interview for Anorexia and Bulimia Nervosa; Tx, treatment; USA, United States of America.

Many studies evaluate eating-related outcomes based on the general Morgan-Russell (M-R) scale or some modification of the scale, which evaluates weight (and menstruation in females), or the average M-R scale, which is a composite rating of subscales measuring nutritional status, mental status, sexual adjustment, menstrual functioning, and socioeconomic status. General scale categories are defined as good—normal body weight and regular menstruation—intermediate, amenorrhea or low body weight (i.e., weight less than 85 percent of average body weight [ABW]); and poor—amenorrhea and low body weight (i.e., less than 85% ABW).

Prospective cohort studies with comparison groups. We included one prospective cohort study with outcomes for individuals with AN in our review that reported results in several articles, after participants were followed for 5 years^345,^ ^356^ and 10 years.^349,^ ^352,^ ^362^ AN participants were 51 residents of Göteborg, Sweden (including three males), born in 1970, who had been diagnosed with AN as adolescents. Comparisons were Göteborg residents matched to the AN group by age, sex, and school attended. Data from all articles discussing this study did not match exactly; therefore, we caution readers about ostensible trends across time based on data from different studies.

At 5-year followup, approximately one-half of the individuals with AN were considered recovered: 59 percent had no eating disorder (ED) diagnosis and 41 percent had a good outcome according to M-R scale criteria. However, 6 percent still had AN and the remainder had other eating disorders including BN (22 percent) and EDNOS (14 percent). The AN group also remained significantly more symptomatic than the nondisease comparison group on several measures such as dietary restriction, concern about body weight, worry about appearance, and Eating Attitudes Test (EAT) scores.

By 10 years, the M-R scale outcomes had improved. One-half of the cohort who had AN at baseline had a good outcome (49 percent); the percentage of the group with a poor outcome had declined from 24 percent at 5 years to 10 percent at 10 years. Still, 27 percent had an ED diagnosis at followup.

Case series studies with comparison groups. One case series study with a nondisease comparison group discussed results in two articles, Bulik et al.^342^ and Sullivan et al.^350^ For this study, investigators recontacted 70 women 12 years after referral for treatment (inpatient, outpatient, or assessment) for AN at one facility in Christchurch, New Zealand. The AN group was not limited to those with adolescent onset of the disease. The comparison group (N = 98) resided in the same city and was matched by age. Although 30 percent of individuals with AN at baseline were fully recovered, 21 percent continued to have an eating disorder at followup, with 10 percent continuing to meet Diagnostic and Statistical Manual, version III, Revised (DSM III-R) criteria for AN. The AN group also continued to exhibit worse eating-related outcomes through other measures. Controlling for age and current AN status, individuals in the AN group reported higher scores on the Eating Disorder Inventory (EDI) drive for thinness and perfectionism subscales and the Three Factor Eating Questionnaire Scale (TFEQ) cognitive restraint and hunger subscales. Similarly, Halmi et al., in a separate US study, found that almost 30 percent of the AN group were recovered at followup.^7^

Case series studies with no comparison groups. Among case series studies with no comparison group, we reviewed three studies limited to patients with adolescent AN onset.^341,^ ^366,^ ^369,^ ^370^ Among a mix of 51 former outpatients and inpatients who were followed from 3.5 to 14.5 years in Norway, Halvorsen et al. found that three-quarters of participants no longer had an ED and had a good M-R general scale outcome score.^366^ Without controlling for the length of followup, patients who no longer had an ED were significantly less likely to be depressed or suffer from an anxiety disorder, with the exception of obsessive-compulsive disorder, which did not differ across groups.

Similarly, after following 95 patients for 10 to 15 years in the US who had all received inpatient treatment, Strober et al. found that three-quarters of participants had achieved full recovery (free of any symptoms of AN and BN for 8 consecutive weeks).^341^ Significant predictors of chronic AN (intermediate or poor outcome) were an extreme compulsive drive to exercise and a history of poor social relating preceding onset of illness. Significant predictors of a longer time to recovery were a more hostile attitude towards one's family and extreme compulsivity in daily routines. In both models, early onset of disease was not a significant predictor.

Using survival analysis, D. Herzog et al. found that a shorter duration of the intake AN episode was a significant predictor of recovery after four years. Other variables in the model that were not significant predictors included age at ED onset, bulimic behaviors, impulse-control behaviors, current depression, and other Axis I disorders.^370^ Again, at 7-year followup, the D. Herzog study found a shorter duration of intake episode and higher percentage of ABW at intake predicted both a shorter time to full recovery and a shorter time to partial recovery.^369^

D. Herzog and colleagues compared outcomes for restricting and for binge/purge subtypes of AN. Not all had received inpatient treatment. At up to 4-year followup, the authors found that the percentage of patients who were fully recovered (asymptomatic for at least 8 consecutive weeks) was greater in the AN-binge/purge subtype (17 percent) than in the AN-restricting subtype (8 percent).^370^ Corresponding to these descriptive differences, the AN-binge/purge group was significantly more likely to have recovered fully than the AN-restricting group (relative risk [RR], 4.6; 95% confidence interval [CI], 0.98–21.9). A much larger percentage achieved partial recovery (did not meet full criteria for AN but still experienced substantial symptomatology); 81 percent in the binge/purge subtype and 54 percent in the restricting group. At 7-year followup, differences between the groups in the percentage that had recovered had diminished; approximately one-third in both subgroups had fully recovered and more than 80 percent had partially recovered.^369^ Forty percent of patients relapsed after first recovery. After following the group for 8 years, differences in duration of disease and ABW predicted being in the binge/purge subtype but measures of impulsivity including a history of alcohol abuse, drug abuse, kleptomania, suicidality, or borderline personality did not.^177^

Through 8-year followup, crossover between the restricting and binge/purge subtypes was high. Of those with the restricting subtype 52 percent changed to the binge/purge subtype, with most of the crossover occurring in the first 5 years of followup.^177^ In contrast, Strober et al. found a lower rate of crossover (29 percent); the median time to onset of binge eating was 24 months.^341^

The remaining case series studies discussing eating-related outcomes are not limited to a sample of patients with adolescent onset of AN. First we report outcomes based on M-R scale criteria because they are the most common measures across studies.

A group of females who had all received inpatient treatment in Heidelberg, Germany, were followed up at several points in time. After 6 years, only 27 percent had a good M-R scale outcome, 25 percent had an intermediate outcome, and 42 percent had a poor outcome.^339^ However, at later followup points, more than 40 percent of living patients had good outcomes.^338,^ ^339,^ ^353,^ ^354^

Among 74 women, 72 percent of whom had received inpatient treatment for AN, followed for an average of 9 years in Hong Kong, bivariate analyses comparing an M-R outcome of good and Shapiro Control Inventory measures found that a good M-R outcome was associated with a better overall general sense of control, a greater positive sense of control, and a lower negative sense of control.^347,^ ^363^ A better M-R outcome was also associated with an initial diagnosis of atypical AN (no fat phobia). Using descriptive analyses, Tanaka et al. found, for patients who all had received inpatient treatment, that a good versus poor M-R outcome was associated with younger age at referral, younger age at admission, higher body mass index (BMI) at followup, higher minimum BMI, better menstrual functioning, and better mental state and psychosocial measures.^351^

Morgan and colleagues used bivariate analyses to report on UK patients followed from 4 to 8.5 years, one-half of whom had been hospitalized.^355^ They reported that lower general M-R outcome scores were associated with longer duration of food difficulties and longer duration of amenorrhea. Poorer average M-R outcome scores were associated with a longer duration of food difficulties, a longer duration of amenorrhea, greater family hostility towards the patient, a disturbed relationship between the patient and family, and personality difficulties.

Ben-Tovim et al. examined the characteristics of the Morgan-Russell-Hayward Scale (M-R-H scale), a modification of the M-R scale, after adding items related to binge eating and vomiting to a subscale concerning dietary and eating patterns, body concern, and body weight.^367^ Using multivariate analyses, the authors found that total M-R-H Scale outcomes were significantly related to the dietary and eating patterns, body concern, and body weight subscale mentioned above. Other subscales measuring menstrual pattern, mental state, psychosexual state, and work and family relations were not significant in the model. Significant predictors in a second model, predicting the same outcome, included subscale 2 at baseline of the disability adjustment scale (measuring overall behavior and social role functioning), the Flinders Medical Centre Symptom Score at baseline (measuring ED symptoms), the Body Attitudes Questionnaire Subscales (measuring a range of body-related attitudes), attractiveness at 6 months, and lastly, change in the salience of weight and shape over the first 6 months of treatment.

Studies also examined diagnostic outcomes, including the persistence of eating disorders over time. Results varied greatly across studies and were not related to length of time to followup. The percentage of individuals who continued to have an AN diagnosis at followup ranged from 9 percent to 29 percent across studies, an EDNOS diagnosis from 2 percent to 36 percent, and no eating disorder from 24 percent to 59 percent of participants.^338,^ ^339,^ ^363,^ ^367,^ ^374^

W. Herzog and colleagues measured change over time in the likelihood of first recovery in the Heidelberg case series, after following patients for a mean of 11.7 years.^359^ The average patient had a first recovery in 5.8 years, with a greater likelihood of recovering in the first 6 years than later. Significant predictors of first recovery in multivariate models were lower serum creatinine levels at baseline, less purging behavior, and the interaction of less purging and fewer social disturbances as measured by the Anorexia Nervosa Symptom Score (ANSS).

Löwe et al. followed this same group of patients for 21 years.^348^ Among the 63 patients, 51 percent showed a good outcome and full recovery, 21 percent were partially recovered, and 26 percent had a poor outcome and 2 percent were unknown. Poor long-term outcome (at 21 years since inpatient admission) was related to low BMI, severe psychological symptoms and social problems, higher EDI perfectionism and interpersonal trust scores, and lower hemoglobin and alkaline phosphatase levels (at 12 years since inpatient admission).

After following this group of patients for 12 years, both Deter and W. Herzog^343^ (N = 84, including deceased patients) and Deter et al.^365^ (N = 70) found that the persistence of AN symptoms was predicted by older age at onset, more somatic symptoms, more laxative use, low albumin levels, and a high value on a global prognosis score developed from the ANSS.^343,^ ^365^ Baseline factors associated with relapsing versus having a persistent disorder include being younger, having a shorter disease duration, and less vomiting.^343^

Eckert et al. found, in descriptive analyses in a group of patients who had received inpatient treatment, that recovered patients were less likely to have major affective disorder, anxiety disorders, and phobias.^338^

Isager and colleagues measured relapse rates (lost 15 percent or more of weight gained during course of treatment in a year's time) among 151 patients (93 percent female) who had received treatment (inpatient or outpatient) in Copenhagen, Denmark.^340^ After following patients from 4 to 22 years, they found patients were experiencing a 3 percent average annual hazard rate of relapse. Relapse was greater among those whose duration of therapeutic contact was less than 1 year.

Other factors related to these types of outcomes include the following. Factors associated with poor Psychiatric Scale Ratings for AN outcomes in the Fichter and Quadflieg study included binge eating in the month before treatment, other mental illness diagnoses before treatment, and lower body weight at the end of treatment.^339^ In research conducted by Lee and colleagues, a group of atypical AN patients scored better at followup on the Eating Attitudes Test - 26 and the Eating Disorders Evaluation Questionnaire.^347,^ ^363^ Typical versus atypical AN patients at followup had a lower sense of control in the domain of body and a stronger desire for control.

Psychiatric/psychological outcomes. Table 30 documents outcomes from eight studies with psychiatric and psychological outcomes.

Table 30 Psychological outcomes: anorexia nervosa

Authors, Year | Country
(Quality Score) | Sample Size | Outcomes
Prospective Cohort, Comparison Group
Gillberg et al., 1995^346^ | Sweden | Years followed (mean): 5
(Good) | Cases: 51 | Diagnoses in AN group*:
| Comparisons: 51 | OCD: 30%, Any cluster C: 37%, any SCID personality disorder: 41%, 2 or more SCID personality disorders: 24%, Asperger syndrome: 12%, any autistic-like condition: 20%; empathy disorder: 30%; OCPD/AS/Autistic-like condition at both age 16 and 21: 45%
Ivarsson et al., 2000^360^ | Sweden | Years followed (mean): 10
(Good) | Cases: 51 | Current diagnoses in AN group*: OCD:16%, axis I disorder (including ED): 53% autism spectrum disorder: 18%, cluster C: 22%,
Nilsson et al., 1999^362^ | Comparisons: 51 | Lifetime diagnoses in AN group*: Any affective disorder: 96% OCD: 35%, OCPD:55%, any anxiety disorder: 57%, Any Axis I (including and excluding ED): 100%, depressive disorder: 84%, cluster C: 63%, autism spectrum disorder: 24%
(Good)
Råstam et al., 2003^349^
(Good)
Wentz et al., 2000^361^
(Good)
Wentz et al., 2001^352^
(Good)
Case Series, Comparisons Groups
Bulik et al., 2000^342^ | New Zealand | Years followed (mean): 12
(Good) | Cases: 70 | Lifetime diagnoses (controlling for age)*:
Sullivan et al., 1998^350^ | Comparisons: 98 | Major depression: Cases: 51%; Comparisons: 36%
(Good) | | Any mood disorder: Cases: 60%; Comparisons: 42%,
| | Alcohol or any drug dependence: Cases: 30%; Comparisons: 12%
| | OCD: Cases: 16%; Comparisons: 2%
| | Separation anxiety disorder: Comparisons: 17%; Comparisons: 2%
| | Overanxious disorder: Comparisons: 37%; Comparisons: 3%
| | Any anxiety disorder: Comparisons: 60%; Comparisons: 33%
Halmi et al., 1991^7^ | USA | Years followed: 10
(Fair) | Cases: 62 | Lifetime diagnoses*:
| Comparisons: 62 | Major depression: Cases: 68%; Comparisons: 21%
| | Dysthymia: Cases: 32%; Comparisons: 3%
| | Obsessive-compulsive disorder: Cases: 25%; Comparisons: 6%
| | Agoraphobia: Cases: 14%; Comparisons: 3%
| | Social phobia: Cases: 32%; Comparisons: 3%
| | Current diagnoses*:
| | Major depression: Cases: 29%; Comparisons: 6%
| | OCD: Cases: 11%; Comparisons: 2%
Case Series, No Comparison Groups
Eddy et al., 2002^177^ | USA | Years followed (median): 8
(Fair) | Cases: 246 | History of drug abuse at intake*:
| | AN restricting pure: 0%; AN restricting not pure: 13%; AN binge purge: 16%
Halvorsen et al., 2004^366^ | Norway | Years followed (mean): 8.8
(Fair) | Cases: 51 | Diagnosis at followup: Depression: 22%; Anxiety (not OCD): 27%; OCD: 2%
| | Diagnoses at followup*:
| | Depression: No ED group: 13%; ED group: 56%
| | Anxiety disorder (no OCD): No ED group: 20%; ED group: 56%
Löwe et al., 2001^348^ | Germany | Years followed (mean): 21
(Fair) | Cases: 63 | Mood disorders by Psychiatric Status Rating Scale outcomes*:
| | Good: 8%; Intermediate: 31%; Poor: 38%
| | Substance use disorders by Psychiatric Status Rating Scale outcomes*:
| | Good: 5%; Intermediate: 6%; Poor: 50%
Strober, Freeman et al., 1996^358^ | USA | Years followed: 10
(Good) | Cases: 95 | Substance use disorder: Abuse: 12%; Dependence: 7%

* Difference between groups (P < 0.05)

AN, anorexia nervosa; AS, Asperger syndrome; CD, compulsive disorder; ED, eating disorder; OCD, obsessive-compulsive disorder; OCPD, obsessive-compulsive personality disorder; sig, significant or significantly; SCID, Structured Clinical Inventory for DSM-IV; USA, United States of America.

Prospective cohort studies with comparison groups. The one prospective cohort study that we reviewed followed individuals, at 5 and 10 years, with AN at baseline and compared them with a matched community comparison group in Göteborg, Sweden.^346^ At 5 years, the AN group was significantly more likely to have various personality disorders including obsessive-compulsive personality disorder, any Cluster C personality disorder (avoidant, dependent, obsessive-compulsive, or passive aggressive), any personality disorder, or two or more personality disorders as measured by the Structured Clinical Interview II for the DSM-IV (SCID II). In addition, individuals in the AN group had significantly greater rates of Asperger syndrome, any autistic-like condition, and empathy disorder than the comparison group.

At 10 years,^349,^ ^352,^ ^361,^ ^362^ the AN group continued to be significantly more likely than the comparison group to currently have a personality disorder, Asperger syndrome disorder or autism spectrum disorder, and lifetime and current obsessive-compulsive disorder. The AN group was not more likely, however, to have an anxiety disorder, excluding obsessive-compulsive disorder.

Ivarsson et al. examined depressive disorders in the AN and comparison groups in these cohorts at both 5- and 10-year followup.^360^ The AN group had a higher lifetime prevalence of depression. Being in the AN group was the only significant predictor of depressive disorder at 5-year followup (odds ratio [OR], 7.7; 95% CI, 1.15–19.6). At 10 years, being in the AN group (OR, 4.03; 95% CI, 1.15–14.19) and having a depressive disorder at 5 years were significant predictors of current depressive disorder. The absence of a mood disorder was significantly associated with resolution of the eating disorder.

Case series studies with comparison groups. Two studies followed individuals with AN who had received treatment and a comparison group. Both found higher rates of lifetime major depression and OCD among the AN group.^7,^ ^342,^ ^350^ The study in Christchurch, New Zealand, which followed women for 12 years, found, after controlling for age, significant differences in the lifetime prevalence of several psychological disorders including major depression, mood disorders, obsessive-compulsive disorder, anxiety disorders, and drug dependence.^342,^ ^350^ The study conducted by Halmi and colleagues also identified that significant differences in the rates of diagnosis of major depression and OCD continued to be true at 10-year followup in their AN case series.^7^

Case series studies with no comparison groups. Descriptively, Eddy et al. found that a history of drug abuse differed among AN subgroups; it was more likely among the binge/purge subtype (16 percent).^177^ Correspondingly, among patients who all had adolescent onset of AN, Strober et al., using stepwise regression, found that binge eating at treatment intake was the only significant predictor of the onset of a substance use disorder. Other variables included in the model, such as depression, anxiety, and weight, were not significant predictors.^358^

Also using stepwise regression, Dancyger et al. measured factors related to Minnesota Multiphasic Personality Inventory (MMPI) scores at 10-year followup on a population of women who had received inpatient treatment and were not limited to those with adolescent onset.^353^ Poorer overall outcomes were related to higher scores on three MMPI subscales: hypochondriasis, paranoia, and psychopathic deviate.

Biomarker-measured outcomes. Table 31 contains study outcomes assessed with biomarkers. This category has very few studies primarily because many studies present measurement of weight and menstrual status through general M-R scale outcomes. These results are included among eating-related outcomes above.

Table 31 Biomarker outcomes: anorexia nervosa

Authors, Year | Country
(Quality Score) | Sample Size | Outcomes
Prospective Cohorts, Comparison Groups
Gillberg et al., 1994^344^ | Sweden | Years followed (mean): 5
(Good)
Gillberg et al., 1994^345^ | Cases: 51 | Near average body weight at FU*: Cases: 53%; Comparisons: 96%
(Good) | Comparisons: 51 | Extremely underweight:* Cases: 8%; Comparisons: 0%
| | Regular or cyclical menstruation*: Cases: 50%; Comparisons: 90%
| | Dysdiadochokinesis*: Cases: 20%; Comparisons: 2%
Råstam et al., 2003^349^ | Sweden | Years followed (mean): 10
(Good)
Wentz et al., 2000^361^ | Cases: 51 | Mean weight: Cases: 62.3 kg; Comparisons: 63.7 kg
(Good) | Comparisons: 51 | Regular or cyclical menstruation*: Cases: 65%; Comparisons: 85%
Wentz et al., 2001^352^ | | Dysdiadochokinesis*: Cases: 22%; Comparisons: 4%
(Good)
Case Series, Comparison Group
Bulik, et al. 2000^342^ | New Zealand | Years followed (mean): 12
(Good)
Sullivan et al., 1998^342^ | Cases: 70 | BMI*: Cases: 20.1 kg/m^2^; Comparisons: 25.6 kg/m^2^
(Good) | Comparisons: 98
Case Series, No Comparison Group
Eckert et al., 1995^338^ | USA | Years followed (range): 8.5–10.5
(Fair) | Cases: 76 | ABW at FU: <85%: 23%; 85%–115%: 73%; >115%: 3%
| | Regular menses: 48%
Löwe et al., 2001^348^ | Germany | Years followed (mean): 21
(Fair) | Cases: 63 | BMI by Psychiatric Status Rating Scale outcomes*:
| | Good: 21.6; Intermediate: 19.7; Poor: 15.3

* Difference between groups (P < 0.05).

ABW, percentage of average body weight; BMI: body mass index; diff, different; FU, Followup; IBW, ideal body weight; kg, kilograms; sig, significant or significantly; USA, United States of America.

Prospective cohort studies with comparison groups. At 5 years, the study of the Göteborg, Sweden, cohort found that the AN group still weighed significantly less than the non-ED comparison group; more of the AN group was appreciably underweight than the comparison, and while only half of the AN group were near average body weight, nearly all of the comparison group were at that weight.^344,^ ^345^ Regular or cyclical menstruation was significantly less likely in the AN group, and a large percentage of the AN group had dysdiadochokinesis (an inability to execute rapidly alternating movements).

At 10 years, various measures of weight, including direct measures in kilograms, ABW, and mean BMI (body mass index), did not differ significantly between groups.^349,^ ^352,^ ^361^ However, a significantly larger percentage of the AN group still did not have normal menstrual function and continued to demonstrate dysdiadochokinesis.

Case series studies with comparison groups. The AN cohort in the Christchurch, New Zealand, study had significantly lower BMI than comparison participants when controlling for age and current AN status.^344,^ ^345^ Desired BMI was also lower in the chronically ill AN group than in recovered individuals or the comparison group.

Case series studies with no comparison groups. Hebebrand et al. examined factors associated with BMI at 0 to 33.6 years followup.^354^ A BMI of less than 17.5 at followup (criterion cutoff for AN diagnosis) was related to lower BMI at referral, older age at referral, and younger age at followup; by contrast, age at disease onset was not a significant predictor. A higher BMI was also found to be significantly related to a better Psychiatric Status Rating Scale outcome at followup.^348^

Eckert et al. followed patients who had received inpatient treatment 10 years previously.^338^ Lower weight was associated with greater food faddishness, laxative abuse, body image disturbance, fear of getting fat, disturbance in sexual adjustment, worse psychological adjustment, disturbed menses, and other weight loss behavior.

Mortality outcomes. Table 32 summarizes results from studies of mortality and risk of suicide in individuals with AN.

Table 32 Mortality outcomes: anorexia nervosa

Authors, Year | Country
Quality Score | Sample Size | Outcomes
Case Series*, No Comparison Groups
Birmingham et al., 2005^3^ | Canada | Years followed (mean): 7
(Fair) | Cases: 326 | Deaths: N=17 (Suicide: N=7, Pneumonia: N=2, Hypoglycemia: N=2, Liver disease: N=2, Cancer: N=2, Alcohol poisoning: N=1, Subdural hemorrhage: N=1)
| | SMR: 10.5
Crisp et al., 1992^357^ | England and Scotland | Years followed (mean): 22
(Fair) | Cases:168 | England: Deaths: N=4 (Anorexia: N=2; Suicide: N=1; Cancer: N=1) (SMR: 1.36 times more likely than women of same age, 1973-1989)
| | Scotland: Deaths N=8 (Anorexia: N=3; Suicide: N=4; Cancer N=1) (SMR: 4.71 times more likely than women of same age, 1973-1979)
Deter et al., 1994^343^ | Germany | Years followed, mean (range): 11.8 (9–19)
(Fair) and Herzog, Schellberg et al., 1997 | Cases: 75 at FU | Deaths: N=9 (AN complications: N=7; Suicide: N=2)
(Fair)
Eckert et al., 1995^338^ | USA | Years followed, mean (range): 9.6 (8.5–10.5)
(Fair) | Cases: 76 | Deaths: N=5 (all complications of AN; no suicides); SMR: 12.8
Eddy et al., 2002^177^ | USA | Years followed, median (range): 8 (8–12)
(Fair) | Cases: 136 | Deaths by subtype: Restricting pure: 8%; Restricting not pure: 8%, Binge/purge: 6%
| | History of suicidality by subtype: Restricting pure: 4%; Restricting not pure: 29%; Binge/purge: 27%
Fichter et al., 1999^339^ | Germany | Years followed (mean): 6.2
(Good) | Cases: 95 | Deaths: N=6 (Traffic accident during exercise: N=1; Cardiac and renal failure: N=2; Hypocalcemia: N=2; Cardiac failure and cachexia: N=1)
Franko et al., 2004^368^ | USA | Years followed (mean): 8.6
(Good) | Cases: 136 | Suicide attempts during study period: 22%
Hebebrand et al., 1997^354^ | Germany | Years followed, mean (range): 9.5, 0–33.6
(Fair) | Cases: 272 | Deaths: N=12 (Emaciation: N=10, Suicide: N=2)
| | Mortality rate by patient weight at referral:
| | < 13 kg/m^2^: 11%, ≥ 13 kg/m^2:^ 0.6%; BMI < 13 at referral associated with higher likelihood of mortality
Herzog et al., 2000^371^ | USA | Years followed: 11
(Fair) | Cases: 110 | Deaths: N=7 (Suicide: N=3; Acute alcohol intoxication: N=1; Cardiorespiratory failure, heptic failure, and cirrhosis: N=1; Cardiac arrhythmia and seizure disorder: N=1; Fungal pneumonia: N=1)
| | SMR (all deaths): 9.6; SMR (suicide): 58.1
Isager et al., 1985^340^ | Denmark | Years followed, mean (range): 12.5 (4–22)
(Fair) | Cases: 142 | Deaths N=9 (Suicide: N=6, Malnutrition: N= 2, Unknown: N=1)
Keel et al., 2003^372^ | USA | Years followed (mean): 8.6
(Fair) | Cases: 136 | Deaths: N=11; SMR: 11.6
| | Suicide: N=4; Suicide SMR: 56.9
Lee et al., 2003^347^ | Hong Kong | Years followed (mean): 9
(Fair) | Cases: 80 | Deaths: N=3 (Suicide: N=2, Emaciation: N=1); SMR: 10.5
Löwe et al., 2001^348^ | Germany | Years followed (mean): 21.3
(Fair) | Cases: 63 at FU | Deaths: N=14 (12 directly due to AN)
Møller-Madsen et al., 1996^364^ | Denmark | Years followed, mean (range): 7.8 (< 1–17)
(Fair) | Cases: 853 | Deaths: N=50 (AN complications: N=13, Natural causes: N=11, Suicide: N=18, Accidents: N=2, Unknown causes or could not be determined: N=4)
| | SMR: Females: 9.2; SMR: Males: 8.2
| | Females only < 1 year following treatment admission, SMR=30.5
Patton, 1988^373^ | United Kingdom | Years followed (mean): 7.6
(Fair) | | Deaths: N = 11 (Suicide: N = 6; low weight: N = 5)
| Cases: 332 | Overall SMR: 6.01; Higher than expected
| | SMR at 4-year FU: 5.76, Higher than expected
| | SMR at 8-year FU: 2.70, Normal level
Sullivan et al., 1998^350^ | New Zealand | Years followed: 12
(Good) | Cases: 70 | Deaths: N = 1 (suidice)
Tanaka et al., 2001^351^ | Japan | Years followed, mean (range): 8.3 (4.0–17.7)
(Fair) | Cases: 61 at FU | Deaths: N=7 (Emaciation: N=3; Suicide: N=2; Murder: N=1; Burn: N=1)

AN, anorexia nervosa; FU, Followup; N, number; sig, significant; SMR, standardized mortality ratio; Tx, treatment; USA, United States of America.

*In case series studies, sample size is as of the date of the analysis and therefore does not include deceased cases.

Prospective cohort studies with comparison groups. No deaths were reported in the Göteborg, Sweden, study through the 10-year followup.

Case series with no comparison groups. All mortality data were obtained from case series studies without a comparison group. Several studies calculated standardized mortality ratios (SMR), allowing for comparison to the population based on age, sex, and time when the patient population was drawn.

The SMRs were elevated in the AN groups and ranged from 9 to 13 across studies.^3,^ ^338,^ ^347,^ ^364,^ ^371,^ ^372^ In one study, SMRs were significantly elevated in a female patient population through 14 years of followup (ranging from 30.5 at less than 1 year followup to approximately 6 for the remainder of the period). The SMR was no longer significantly elevated after 14 years.^364^

Only in two studies conducted in the United Kingdom were the SMRs lower. Crisp et al. examined mortality among females more than 20 years after they had received treatment for AN in either London, England (1968 to1973), or Aberdeen, Scotland (1965 to 1973).^357^ In England, women with AN were 1.36 times more likely to die than women of the same age in England and Wales between 1973 and 1979. In Scotland, women with AN were 4.71 times more likely to die than women of the same age in Scotland during the same period.

Patton and colleagues conducted a record review of 332 AN patients, mostly female (96 percent), who had received treatment at Royal Free Hospital in the United Kingdom between 1971 and 1981.^373^ The SMR at 4-year followup was 5.76, which was a significant elevation; at 8-year followup, the SMR was 2.7 (not significant). Predictors of mortality included weight less than 35 kilograms at presentation and more than one inpatient admission.

In one study that followed patients for 8.6 years, significant predictors of death (controlling for age and duration of illness before intake) included greater severity of alcohol use disorders, greater severity of substance use disorders, worse social adjustment, and worse global assessment of functioning (GAF) scores. Predictors of shorter time to death included longer duration of illness at treatment intake, affective disorder hospitalization at intake, suicidality associated with mental illness other than an ED, substance abuse, and worse severity of alcohol use over the course of the illness.^372^ Descriptively, Isager et al. found that deceased patients were significantly more likely to have been hospitalized.^340^

Suicide was a common cause of death. Among the group of females with adolescent AN onset who received ED treatment at the Massachusetts General Hospital or other Boston area clinics the SMR was 58.1, significantly higher than that for the population as a whole.^371^

Franko et al. reported predictors of suicide attempts among the women in the Boston cohort.^368^ Thirty percent of their patients had a history of suicide attempts before they entered the study; during the study, 22 percent of AN patients attempted suicide. A history of a suicide attempt at intake significantly predicted time to a future attempt in individuals with AN. Using multiple regression techniques, the authors determined that a first suicide attempt was predicted by a history of suicide attempts at intake, greater drug use, participation in individual therapy, use of neuroleptic medications, and older age at disease onset.

A history of suicidality was significantly different among patient subtypes in one study - lower in the pure restricting group than other groups.^177^ However, the groups did not differ in rates of death at 8-year (median) followup.

Several other case series studies that were discussed in relation to their eating, psychological, or biomarker outcomes reported deaths of patients during the followup period. These are summarized in Table 32.

Summary of studies addressing KQ 5. One prospective cohort study following individuals who had AN and a healthy comparison group has been conducted. Limited to individuals with adolescent onset of their illness and comparisons in Göteborg, Sweden, this study found that, over a 10-year period, approximately one-half of the group had fully recovered; a small percentage continued to suffer from AN, and the remainder still had other eating disorders. The AN group no longer differed from the comparison group in terms of weight but these individuals continued to be more depressed than comparisons and to suffer from a variety of personality and obsessive-compulsive disorders, Asperger syndrome, and autism spectrum disorders.

Two case series studies, which gathered followup measures from individuals who had received treatment for AN and a nondisease comparison group, were reviewed. They concluded that individuals with AN continued to be more likely to have eating and comorbid psychiatric diagnoses years after treatment. In one study, lower desired body weight and lower desired and actual BMI continued in the AN group, after controlling for current AN status. Individuals in the AN group were also more likely to be depressed and to suffer from mood and anxiety disorders. The second study, limited to psychiatric outcomes, found continued higher rates of major depression and obsessive-compulsive disorder.

The remaining studies had no comparison groups. Rates of recovery and good outcomes varied across studies. Only a relatively small percentage of patients continued to be diagnosed with AN or BN at long-term followup, but many continued to have eating disorders, and relapse rates were high. We did not find evidence that age of disease onset was related to disease chronicity. A relatively large percentage of patients cross over from the restricting subtype to the binge/purge subtype of the disease, but results are mixed concerning which subtype has better eating outcomes.

Few studies examined psychiatric and psychological comorbidities independently of their relationship to eating disorder outcomes. Among those that did and had a comparison group, individuals with AN had a higher probability of having a depression and anxiety disorders diagnosis (including obsessive-compulsive disorder) than comparison individuals. Based on the results of one cohort study, individuals with AN may also be more likely to have Asperger syndrome or autism spectrum disorder. Among individuals with AN, substance abuse may be associated with binge eating.

Through at least 5 years of followup, individuals with AN are more likely to weigh less than comparisons and evidence suggests that their desired weight is lower. We did not find similar predictors of continued low weight in the AN case series studies and so are unable to draw conclusions concerning these relationships. However, some evidence exists that lower weight at treatment presentation is related to poorer outcomes.

The mortality risk is significantly greater among those diagnosed with AN than in the population as a whole. The risk of suicide is particularly pronounced, as is the risk of death early in the followup period. Increased risk is associated with alcohol and substance use disorders.

### Key Question 6: Outcome Difference by Sex, Gender, Age, Race, Ethnicity, or Cultural Group

We examined whether AN outcomes differed by participants' sex, gender, age, race, ethnicity, or cultural groups. We found insufficient evidence to evaluate differences by sex or gender. Males were included in only 19 of 38 reviewed studies and were never more than 10 percent of the analysis sample in any one study. No study included any analyses examining differences controlling for sex or gender.

No study that we reviewed provided outcomes based on the age of the participant at followup. Some studies limited participants to those whose AN onset was during adolescence, but none compared outcomes of those with adolescent onset to those with older onset. However, six studies did include a measure of age at disease onset. Whether this is a significant factor in the course of AN is of particular interest in the field.

Results were mixed. Descriptively, Tanaka et al. found that a good M-R rating was related to younger age at referral;^351^ Deter and Herzog found that earlier onset of disease was a significant predictor of AN symptoms at 12-year followup.^343^ Suicide attempts were more likely among those whose disease began at an older age.^368^ In contrast, Strober et al. did not find age at onset to be a significant factor in predicting chronic AN (intermediate or poor outcomes) at 10- to 15-year followup.^341^ It was also not a predictor of time to recovery after 4 years in the Heidelberg case series.^370^ Lastly, although Hebebrand et al. found age at onset not to be significantly related to lower BMI at followup,^354^ they reported that older age at referral and younger age at followup predicted worse outcome.

Only two studies, both from the United States, reported the race or ethnicity of participants. Nonwhite subjects constituted 4 percent of the Boston, Massachusetts, case series^368^ and 7 percent of the case series from the University of California at Los Angeles.^341,^ ^358^

## Bulimia Nervosa

Our discussion of BN outcomes includes 14 articles exclusively discussing individuals with BN^70,^ ^333,^ ^375^–^385^ and seven articles discussing individuals with both AN and BN.^367^–^373^ As above for AN, we first discuss results for KQ 5, then results for KQ 6.

### Key Question 5: Factors Associated with Outcomes

Eating-related outcomes. Table 33 summarizes results from studies that report eating-related outcomes. The BN literature that met our inclusion criteria included only case series studies (i.e., no cohort studies). One study had a nondisease comparison group; all other studies had no comparison group.

Table 33 Eating-related outcomes: bulimia nervosa

Authors, Year | Country
(Quality Score) | Sample Size | Outcomes
Case Series, Comparison Groups
Fichter and Quadflieg, 2004^378^ | Germany | Years followed: 12
(Fair) | Cases: 163 | Case diagnosis at 6 year FU: Recovered/no ED: 67%; AN: 4%; BN purge: 21%; BN nonpurging: 1%; BED: 1%; EDNOS: 1%;Deceased: 1%
| Comparisons: 202 | Case diagnosis at 12 year FU: Recovered/no ED: 66%; AN: 2%; BN purge: 10%; BN nonpurging: 1%; BED: 2%; EDNOS: 14%; Deceased: 3%
Case Series, No Comparison Groups
Ben-Tovim et al., 2001^367^ | Australia | Years followed: 5
(Good) | Cases: 86 | Diagnosis at FU: AN: 1%; BN: 8%; EDNOS: 13%; No ED:74%; Unknown: 5%; Deceased: 0
| | M-R-H Outcomes: Good: 76%; Intermediate: 19%; Poor: 2%; Unknown: 2%
Fairburn et al., 2000^375^ | United Kingdom | Years followed: 5
(Good) | Cases: 92 | Diagnosis at FU: BN: 15%; BED: 7%; AN: 1%; EDNOS: 32%
Fairburn et al., 2003^377^ | | Any DSM-IV ED: 49%; Remission: 35%; Relapse: 26%
(Good)
Stice and Fairburn, 2003^386^
(Fair)
Fichter and Quadflieg, 1997^70^ | Germany | Years followed (mean): 6.2
(Fair) | Cases: 185 | Diagnosis at 2 years FU: AN: 2%; BN: 36%; EDNOS: 8%; No ED: 55%
| | Diagnosis at 6 years FU: AN: 4%; BN: 21%; BED: 1%; EDNOS: 2%; No ED: 71%
Herzog et al., 1993^380^ | USA | Years followed: 1
(Good) | Cases: 96 | First shift to subclinical BN diagnosis (loss of full criteria without considering duration): 86%
| | Partial recovery: 71%; Full recovery: 56%
Herzog et al., 1996^370^ | USA | Years followed: 4
(Good) | Cases: 150 | Partial recovery: 88%; Full recovery: 57%
Herzog et al., 1999^369^ | USA | Years followed (Median): 7.5
(Good) | Cases at baseline: 110 | Full recovery: 74%; Partial recovery: 98%; Relapse after full recovery: 35%
Jäger et al., 2004^381^ | Germany | Years followed: 8
(Fair) | Cases: 80 | Diagnosis at FU: BN: 29%; EDNOS (bulimic): 9%; EDNOS (anorexic): 1%; No ED diagnosis: 61%
| | No binges per week at FU: 63%
Keel et al., 1999^384^ | USA | Years followed (mean): 11.5
(Fair)
Keel, Mitchell, Davis et al., 2000^383^ | Cases: 173 | Diagnosis at FU: BN: 11%; AN:1%; BED: 1%; EDNOS: 19%; lifetime history of AN: 36%; lifetime history of BED: 11%
(Fair)
Keel, Mitchell, Miller et al., 2000^385^ | | Narrow definition of remission: Full: 42%, Partial: 28%
(Fair) | | Broad definition of remission: Full: 47%, Partial: 23%

AN, anorexia nervosa; BED, binge eating disorder; BN, bulimia nervosa; DSM-IV, Diagnostic and Statistical Manual for Mental Disorders, Fourth Edition; ED, eating disorder; EDNOS, eating disorder not otherwise specified; FU, followup; M-R-H Scale, Morgan-Russell-Hayward Scale; USA, United States of America.

Case series studies with comparison groups. Female patients who had received inpatient treatment (N = 163), in Germany were followed for 12 years.^378^ The comparison group (N = 202) included females ages 18 to 30 who had never received treatment for an eating disorder. The Structured Inventory for Anorexic and Bulimic Syndromes, Expert-Rating version (SIAB-EX) was used to compare eating disorder symptoms between cases and comparisons at 12 year followup. The BN group as a whole was significantly more symptomatic than the comparison group, as were individuals with BN who were considered to be recovered.

As shown in Table 33, the BN group improved over time. At 2 years, 53 percent were considered recovered and did not have any ED diagnosis. At 6 years, the same was true of 67 percent of the women and, at 12 years, of 66 percent of the women.^378^ However, even though recovery rates improved over time, total EDI scores were worse at 2- and 6-year followup than at discharge.^70^

Lifetime psychiatric comorbidity predicted a significantly higher probability of having any eating disorder at 2- and 6-year followup. This variable was no longer significant at 12 years. In contrast, after 12 years, greater lifetime psychiatric comorbidity significantly predicted a higher probability of having a global eating disorder outcome as measured by the Psychiatric Status Rating Scale (PSR) (OR, 3.71; 95% CI, 1.16–11.91). A lifetime history of AN and older age at disease onset also predicted a worse PSR at 12 years.^378^

Case series studies with no comparison groups. Fairburn and colleagues conducted 5- and 6-year followup assessments of females recruited for two psychotherapy trials in the United Kingdom.^375^–^377,^ ^386^ The investigators recruited 102 patients with BN through general practitioners and psychiatrists with no limitations on age at disease onset.

After 5 years, by a variety of measures, the group had improved since baseline and had experienced a significant reduction, in the previous 3 months, in mean objective bulimic episodes, self-induced vomiting episodes, and laxative misuse.^375^ Eating Disorder Examination (EDE) interview measures that significantly improved included those measuring restraint, shape concern, weight concern, and eating concerns.

Fairburn et al. examined whether outcomes differed between persistent disease (at least two episodes of behavior at one or both of last two assessments) and remitted disease (not engaged in any relevant behavior over past 3 months); they focused solely on binge eating or compensatory behaviors.^377^ The persistence of binge eating behavior was related to baseline duration of disturbed eating, overvaluation of shape and weight, and worse social adjustment. None of the tested baseline factors predicted compensatory behavior. However, binge eating and compensatory behaviors were significant predictors of each other.

At 6-year followup, using multivariate analysis, Fairburn, Norman et al. determined that significant predictors of current AN or BN status (adjusted for the type of treatment received and the duration of followup) included paternal obesity (OR, 5.73; 95% CI, 1.56–21.1) and premorbid obesity (OR, 4.31; 95% CI, 1.35–13.7).^376^

Stice and Fairburn categorized their BN patients into dietary and dietary-depressive subtypes using cluster analysis.^386^ Compared with persons in the dietary subtype, those in the dietary-depressive subtype were significantly more likely to have lifetime psychiatric treatment for eating disorders at baseline and during followup, greater persistence of binge eating and compensatory behaviors, and diagnoses of major depression, panic disorder, obsessive-compulsive disorder, social phobia, generalized anxiety disorder, and agoraphobia.

D. Herzog and colleagues examined eating-related outcomes for a group of female patients who sought treatment at Massachusetts General Hospital and other Boston area ED programs.^369,^ ^370,^ ^380^ The authors examined levels and predictors of full and partial recovery at 1, 4, and 7 years. Full recovery was defined as 8 consecutive weeks of being asymptomatic; partial recovery was defined as not meeting full criteria for AN or BN but still experiencing significant symptomatology.

The percentage of the group that fully recovered increased over time. At 1 year, 56 percent were fully recovered;^380^ at 4 years, 57 percent were fully recovered;^370^ and at 7 years, 73 percent had achieved a full recovery at some point during followup.^369^ The trend was similar for partial recovery at some point during followup: 1 year, 71 percent;^380^ 4 years, 91 percent;^370^ and 7 years, 98 percent.^369^ Recovery was not, however, necessarily persistent even if it covers 8 consecutive weeks. By 7 years, 35 percent had relapsed after achieving a full recovery.

The authors investigated predictors of recovery at each followup. At 1 year, ideal body weight (IBW) was not a significant predictor of time to partial recovery.^380^ Variables included in their models at both 4- and 7- year followup included duration of the current disorder episode, age at onset of the current eating disorder, age at onset of the first eating disorder, weight, binge and purge frequency, and the co-occurrence of various other disorders including those involving a lack of impulse control, depression, personality and any Axis I disorder. At both points, no significant predictors of recovery emerged from among these variables.^369,^ ^370^

Ben-Tovim et al. analyzed results from 86 female BN patients who had been treated by an eating disorder specialist in Adelaide, South Australia, and followed for 5 years.^367^ Not all had inpatient stays and age at onset was not reported. Using multivariate analyses, they reported that total M-R-H scale outcomes were significantly related to subscales for dietary and eating patterns, body concern, and body weight rather than other subscales concerning menstrual pattern, mental state, psychosexual state or work and family relations. In a second multivariate model, M-R-H total scores were predicted by overall behavior and social functioning at baseline, feeling fat at study recruitment, attractiveness at 6 months, and change in depression over the first 6 months.

Jäger et al. compared outcomes of female patients who had received analytic inpatient and systemic outpatient treatment at a hospital in Germany.^381^ Over time, binges, bulimia severity, the number of episodes of food restriction, and EAT measures of bulimia and dieting significantly decreased in both treatment groups; in addition, the number of normal meals increased. The group receiving analytic inpatient treatment had a greater decline in the severity index and the number of restrictions than the group receiving systemic outpatient therapy.

Keel and colleagues examined eating-related outcomes for 173 females with a mean of 11.5 years following evaluation at the University of Minnesota's Eating Disorders Clinic.^383^–^385^ Members of the group had participated in one of two previous treatment studies. A particular interest in this study was comparing results based on different definitions of remission. Defining remission as freedom from disordered eating for at least 6 months and the absence of undue influence of shape and weight on self-evaluation, the authors reported that 42 percent were in full remission and 28 percent in partial remission. Using a broader definition of remission, including absence of disordered eating for at least 8 weeks with no restrictions based on the influence of weight and shape, they reported 47 percent were in full remission and 23 percent were in partial remission.^384^

The authors compared the relation between prognostic factors and two specifications of the outcome measure: categorical (full or partial remission vs. not in remission) and continuous (log of the number of months since last binge/purge episode).^384,^ ^385^ The two models showed little difference in results. Significant factors in relation to both outcome specifications included lifetime substance use, baseline substance use, current mood, substance use, and impulse control disorders, and results on a multidimensional personality questionnaire. Prognostic factors that were not statistically significant in relation to either outcome specification included age at onset, duration of symptoms at baseline, baseline depression or anxiety disorder, and lifetime mood or anxiety disorder.

Keel et al. compared the association among six definitions of BN outcomes and a variety of other outcome measures and prognostic variables.^383^ Definitions of BN outcomes varied based on the duration of abstinence required for full remission or recovery, the number of categories in which outcomes were placed, and how the categories were combined. Full recovery ranged from 47 percent to 38 percent based on the required duration of abstinence in the specification. Other outcomes that were significantly related to the eating disorder outcome in all specifications included depression, body image disturbance, impulse control, and social adjustment. The analysis did not identify any prognostic factors that were statistically significant in relation to all six eating disorder specifications. However, substance abuse was significant in four of six specifications, age of presentation in three specifications, and age of onset in two.

Including 101 of the females from the University of Minnesota study discussed above, Keel et al. also examined the independence and relative strength of depression compared with bulimic symptoms in predicting body dissatisfaction at followup.^382^ Baseline depression was both independent of and superior to bulimic symptoms in predicting body dissatisfaction at followup, demonstrating a direct association between depression and body dissatisfaction that is independent of bulimic symptoms.

Psychiatric/psychological outcomes. Table 34 summarizes results from studies reporting psychiatric/psychological outcomes.

Table 34 Psychological outcomes: bulimia nervosa

Authors, Year | Country
(Quality Score) | Sample Size | Outcomes
Case Series, Comparison Groups
Fichter and Quadflieg, 2004^378^ | Germany | Years followed: 12
(Fair) | Cases: 163 at 12 year followup | Psychiatric comorbidity at followup:
| | Lifetime 79.7%; current: 41.1%
| | Mood disorders: Lifetime: 69.0%; current: 16.5%
| Comparisons: 202 | Major depression: Lifetime: 58.2%; current: 10.8%
| | Anxiety: Lifetime: 36.1%; current: 22.2%
| | Substance use: Lifetime 36.1%; current: 14.6%
| | Borderline personality disorder: 9.5%
Case Series, No Comparison Groups
Fichter and Quadflieg, 1997 | Germany | Years followed (mean): 6
(Fair) | Cases: 185 | Psychiatric comorbidity at 2-year followup:
| | Borderline personality disorder: 5%; Substance abuse: 24%; Mood disorders: 30%; Anxiety disorders: 13%
| | Psychiatric comorbidity at 6-year followup:
| | Borderline personality disorder: 4%; Substance abuse: 21%; Mood disorders: 46%; Anxiety disorders: 32%
Stice and Fairburn, 2003 | United Kingdom | Years followed: 5
(Fair) | Cases: 82 | Psychiatric comorbidity at followup:*
| | Major depression: Dietary: 61%; Dietary-depressive: 81%
| | Panic disorder: Dietary: 15%; Dietary-depressive: 33%
| | Obsessive-compulsive disorder: Dietary: 2%; Dietary-depressive: 25%
| | Generalized anxiety disorder: Dietary: 11%; Dietary-depressive: 47%
| | Agoraphobia: Dietary: 4%; Dietary-depressive: 36%

* Difference between groups (P < 0.05).

Prospective cohort studies with comparison groups. The Fichter and Quadflieg study that followed females with BN and a healthy comparison group recorded psychiatric comorbidities in the BN group only.^70,^ ^378^ In the first 6 years after treatment, general psychopathology, as measured by the Symptom Checklist 90-Revised (SCL-90), found that symptoms were worse at 2-year followup but better at 6-year followup compared to the end of treatment.^70^ At 12 years, 80 percent of patients had a lifetime psychiatric disorder, and 41 percent had a psychiatric disorder in the month before assessment. Half of the patients had suffered from a lifetime mood disorder or major depression and 36 percent had suffered from an anxiety or substance use disorder.^378^

Case series studies with no comparison groups. The Jäger et al. study that reported 8-year outcomes following either analytic inpatient or systemic outpatient treatment found that depression had declined in both groups^381^ but that the decline was greater in those who received inpatient treatment.

Biomarker measured outcomes. Table 35 presents results from studies with outcomes assessed through various biomarkers.

Table 35 Biomarker outcomes: bulimia nervosa

Authors, Year | Country
(Quality Score) | Sample Size | Outcomes
Case Series, No Comparison Groups
Fairburn et al., 2000^375^ | England | Years followed: 5
(Good) | Cases: 92 | Change over time:
| | Weight: 69.8 kg, BMI: 25.5
Fichter and Quadflieg, 1997 | Germany | Years followed (mean): 6
(Fair) | Cases: 185 | Weight at followup: Good (19<BMI<30): 74%; Intermediate (BMI 30–40 or 17.5–19): 17%; Poor (BMI<17.5 or >40): 9%
Gendall, Bulik et al., 2000^379^ | New Zealand | Years followed: 1
(Good) | Cases: 82 | Irregular menses: 30.5%
Keel et al., 1999^384^ | USA | Years followed (mean): 11.5
(Fair) | Cases: 173 | BMI: 22.1, Weight: 60.7 kg

2 BMI, Body mass index, measured in kg/m; USA, kg, kilograms; United States of America.

Case series studies with no comparison groups: Gendall et al. followed 82 females for 1 year who had participated in outpatient treatment trials in New Zealand.^379^ At followup, approximately 31 percent of the female participants had irregular menses. In multivariate analyses, irregular menses (irregular or absent menstrual cycles within the past 3 months) were significantly related to a greater maximum-minimum weight difference and current smoking.

Several studies reported improvements over time in weight measures. After 5 years, Fairburn and colleagues found that participants' mean weight and BMI had increased.^375^ At 6-year followup, Fichter and Quadflieg found that 74 percent of their participants were in the good weight range.^70^ Similarly, Keel et al. measured differences in weight variables in 173 females followed for approximately 11 years.^384^ BMI, actual weight, desired weight, and highest weight all significantly increased over time.

Mortality outcomes. Table 36 gives the results from studies that reported on either death or risk of suicide (or both) among individuals with BN.

Table 36 Mortality outcomes: bulimia nervosa

Authors, Year | Country
Quality Score | Sample Size | Outcomes
Case Series Studies, Comparison Groups*
Fichter and Quadflieg, 2004^378^ | Germany | Years followed: 12
(Fair) | Cases: 163 at 12 year followup | BN Cases Deaths:
| | 2 year followup: 0
| | 6 year followup: 2
| Comparisons: 202 | 12 year followup: 4, SMR: 2.36
Franko et al., 2004^368^ | USA | Years followed: 8.6
(Good) | Cases: 110 | Suicide attempts: 11%
| | Predictors of time to first suicide attempt (adjusted):
| | Group therapy; Younger age at onset; History of drug use disorder; Individual therapy; Paranoid personality disorder; Greater severity of laxative use
Herzog, et al., 2000^371^ | USA | Years followed: 11
(Fair) | Cases: 110 | Loss to followup deaths: 0
Keel et al., 2003^372^ | USA | Years followed (Median): 9
(Fair) | Cases: 110 | Deaths: 1, SMR: 1.3
Patton et al. 1988^373^ | USA | Years followed: 4–15
(Fair) | Cases: 96 | Deaths: N=3 (2 car accidents, 1 low weight)
| | Crude mortality rate: 3.3, SMR: 9.38

BN, bulimia nervosa; SMR, standardized mortality ratio; USA, United States of America.

* In case series studies, sample size is as of the date of the analysis and therefore does not include deceased cases.

Case series studies with comparison groups. In the Fichter and Quadflieg study, 2.5 percent of the BN group were deceased at 12-year followup.^378^ The SMR was 2.36, not significantly different from the rate expected in the population matched by age and sex.

Case series studies with no comparison groups. Franko et al. reported predictors of suicide attempts in a group of 110 women with BN who had been recruited because they sought treatment for eating disorders at Massachusetts General Hospital and other Boston area clinics.^368^ At baseline, 23 percent reported a history of suicide attempts before assessment, and 11 percent reported suicide attempts during the study. After approximately 9 years of followup, significant predictors of shorter time to first suicide attempt included receiving group therapy, receiving individual therapy, younger age at onset, a history of drug use disorder, paranoid personality disorder at intake, and greater severity of laxative use.

In a companion study, D. Herzog et al. followed this same group of women in Boston for 11 years to examine rates and causes of death.^371^ At the end of that time, none of the women were deceased.

Keel et al. measured the mortality rates among 110 females, also recruited in Boston, in the same manner as Herzog et al., but the parameters of the recruitment dates differed somewhat. Participants were followed for a median of 9 years.^372^ One individual died during the followup period. The SMR of 1.3 was not significantly different from what would be expected in the population as a whole.

Patton et al. measured mortality rates in patients in the United Kingdom who were followed for 4 to 15 years.^373^ Three patients died during the observation period, one from low weight. Again, the SMR was not statistically significant from what would be expected in the healthy population.

Summary of findings. All of the BN literature is case series, that is, studies that follow individuals over time who have received treatment. One study included a nondisease comparison group. Much of the emphasis in the BN literature concerned comparing various definitions of disease outcomes and diagnostic subtypes. Generally in these studies, more than half of the patients followed no longer had a BN diagnosis at the end of the study period. A substantial percentage continued to suffer from other eating disorders, but BN was not associated with an increased mortality risk. A limited number of analyses uncovered factors significantly associated with outcomes of this disease. Only depression was associated with worse outcomes consistently across studies.

### Key Question 6: Outcome Difference by Sex, Gender, Age, Race, Ethnicity, or Cultural Group

In each of the BN outcomes studies except for Patton et al., all participants we reviewed were female.^373^ Four percent of the participants in the Patton et al. study were male; however, this study included both AN and BN populations, and the authors do not specify how many of the included males were in each disorder group.

Most studies did not report the race, ethnicity, or cultural group of the participants. Franko et al. reported that 4 percent of their sample was nonwhite, but they did not specify the distribution in the BN sample, relative to the AN sample.^368^ Johnson and colleagues reported that the modal race was white;^333^ Keel and colleagues reported that 1 percent of their sample was nonwhite.^384^ These investigators did not, however, report outcome differences by race, ethnicity, or cultural group. No outcome studies of BN controlled for the age of participants at entry; no studies were limited to individuals with adolescent onset of the disorder. We conclude that no evidence exists to determine whether outcomes for BN differ by any of these categories.

## Binge Eating Disorder

Given the recent addition of the provisional criteria for BED to the psychiatric nomenclature, three studies met our inclusion criteria for this section. All three studies were case series.^387^–^389^ One study included a comparison group.^389^ One study was conducted in the United States (rated as fair),^388^ one in Germany (rated as fair),^387^ and one in Italy (rated as fair).^389^

### Key Question 5: Factors Associated with Outcomes

In KQ 5 we address outcomes of BED and factors associated with outcomes. We partitioned outcomes into eating-related outcomes, psychological outcomes, and biomarker outcomes (largely weight change).

Case series with comparison groups. The only case series with a comparison group explored a special population of individuals undergoing laparoscopic adjustable gastric banding.^389^ This is an important research question intended to determine whether individuals with BED who are obese are appropriate for bariatric surgery. In this large study of 130 BED patients versus 249 obese comparison individuals without BED, those with BED experienced more band adjustments and more pouch and esophageal dilatations than those without BED. The authors did not report on psychological outcomes. At 5 years, the groups did not differ on measures of either weight loss or weight regain. The authors did not report on any variations in disordered eating behavior that may have persisted after bariatric surgery.

Case series without comparison groups. Fichter et al.^387^ followed 62 cases with BED for 6 years; of these patients, 78 percent had no ED diagnosis, 6 percent continued to have a BED diagnosis, and a minority had developed BN or EDNOS over the followup interval. Over the 6-year interval, depression, anxiety, and obsessionality measures also improved. The authors did not report whether changes observed in BMI over time were significant. No additional factors associated with outcome were reported.

The second case series examined the impact of comorbid psychopathology and personality disorders on treatment outcome for BED.^388^ Individuals with cluster B personality disorders reported a greater number of binge days at 1-year followup. Neither binge frequency nor EDE global scores were related to other comorbid conditions. The authors did not report additional psychological or biomarker outcomes.

Summary of studies addressing KQ 5. Only sparse evidence addresses factors associated with BED outcomes. The three included studies have vastly different designs and research questions; more importantly, their findings do not converge.

### Key Question 6: Outcome Difference by Sex, Gender, Age, Race, Ethnicity, or Cultural Group

KQ 6 addresses whether outcomes differ for BED by sex, gender, age, race, ethnicity, or cultural groups In all, 405 women and 134 men participated in outcome studies of BED. No study compared differential factors associated with outcome by sex or gender.

Only one study reported ethnicity:^388^ 151 whites, five blacks, four Hispanics, and two Native Americans. This study did not report any differential outcomes by ethnicity.

All three studies were of adults. No outcome studies of BED in children have been performed. Nothing is known about differential outcome by age group.