# Results: Binge Eating Disorder

This chapter presents results of our literature search and our findings for the four key questions (KQs) pertaining to binge eating disorder (BED). KQ 1 sought evidence for the efficacy of various treatments or combinations of treatments for BED. KQ 2 sought evidence of harms associated with the treatment or combination of treatments for BED. KQ 3 addressed factors associated with the efficacy of treatment for BED. KQ 4 addressed whether the efficacy of treatment for BED differs by sex, gender, age, race, ethnicity, or cultural groups. We report first on specific details about the yields of the literature searches and characteristics of the studies, then on literature pertaining to treatment (KQ 1, KQ 2, and KQ 3). Summary tables presenting findings grouped by selected outcomes appear at the end of this chapter.

## Overview of Included Studies

For each included BED study, detailed evidence tables appear in Appendix C.^††^ We report first on medication trials (Evidence Table 10), then combined medication and behavioral interventions (Evidence Table 11), behavioral interventions only (Evidence Table 12), self-help interventions (Evidence Table 13), and other interventions (Evidence Table 14). Within each table, studies are listed alphabetically by author. For each study we report eating disorder-related outcomes, psychiatric and psychological outcomes (such as comorbid depression and anxiety), and biomarker outcomes including weight loss.

†† Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/eatingdisorders/eatdis.pdf..

We identified 26 studies addressing treatment efficacy for BED. Nine were medication-only trials.^305^–^313^ We rated four of these trials as good,^305,^ ^307,^ ^309,^ ^312^ and five as fair.^306,^ ^308,^ ^310,^ ^311,^ ^313^ One study of a medication no longer available in the United States (d-fenfluramine) is not discussed here.^313^ The medications studied included second-generation antidepressants,^305^–^309^ tricyclic antidepressants,^310^ an anticonvulsant,^311^ sibutramine,^312^ and d-fenfluramine.^313^

Four trials combined medication with behavioral interventions using second-generation antidepressants,^314,^ ^315^ a tricyclic antidepressant,^316^ and orlistat.^317^ Of these, we rated two as good,^315,^ ^317^ one as fair,^316^ and one as poor.^314^

We identified eight behavioral-intervention-only studies. Of these, we rated one trial as good,^318^ three as fair,^319^–^321^ and four as poor.^322^–^325^ Of the four fair or good studies, three used some form of cognitive behavioral therapy (CBT) in comparison to other interventions^318^–^320^ and one used dialectical behavior therapy (DBT).^321^

Three trials investigated various self-help methods.^326^–^328^ We rated one as good^326^ and two, which report on the same sample at two points in time, as fair.^327,^ ^328^ Finally, one trial involved exercise, rated as poor,^329^ and another examined virtual reality therapy, rated as fair.^330^

Studies with a quality rating of “poor” are not discussed below. Reasons that these studies received this rating are presented in Table 20. Although each study was not deficient in all areas, the following are the most common concerns contributing to the low rating of studies: randomization (no description of protections against researchers' influence, a fatal flaw in approach or the approach not described), assessors not being blinded or their blinding status not described, adverse events not described, the statistical analysis not including or not reporting whether a power analysis was conducted, a lack of necessary controls for confounding, and results not reported using an intention-to-treat approach.

Table 20 Reasons for poor quality ratings and number of trials with poor ratings: binge eating disorder

Reasons Contributing to Poor Ratings | Types of Intervention, Number of Times Flaw Was Detected, and Citations
Research Aim
Hypothesis not clearly described | Medication-only trials: 0
| Psychotherapy trials: 0
Study Population
Characteristics not clearly described | Medication-only trials: 0
| Psychotherapy trials: 0
No specific inclusion or exclusion criteria | Medication-only trials: 0
| Psychotherapy trials: 0
Randomization
Protections against influence not in place | Medication-only trial: 1^314^
| Psychotherapy trials: 3^322^–^324^
Approach not described | Medication-only trials: 0
| Psychotherapy trials: 1^324^
Whether randomization had a fatal flaw not known | Medication-only trials: 0
| Psychotherapy trials: 4^322^–^325^
Comparison group(s) not similar at baseline | Medication-only trials: 0
| Psychotherapy trials: 0
Blinding
Study subjects | Medication-only trials: 1^314^
| Psychotherapy trials: 0
Investigators | Medication-only trials: 1^314^
| Psychotherapy trials: 0
Outcomes assessors | Medication-only trial: 1^314^
| Psychotherapy trials: 4^322^–^325^
Interventions
Interventions not clearly described | Medication-only trials: 0
| Psychotherapy trials: 0
No reliable measurement of patient compliance | Medication-only trials: 0
| Psychotherapy trials: 2^322,323^
Outcomes
Results not clearly described | Medication-only trials: 0
| Psychotherapy trials: 0
Adverse events not reported | Medication-only trials: 0
| Psychotherapy trials: 3^322^–^324^
Statistical Analysis
Statistics inappropriate | Medication-only trials: 0
| Psychotherapy trials: 1^325^
No controls for confounding (if needed) | Medication-only trials: 0
| Psychotherapy trials: 2^323,325^
Intention-to-treat analysis not used | Medication-only trials: 0
| Psychotherapy trials: 3^323^–^325^
Power analysis not done or not reported | Medication-only trial: 1^314^
| Psychotherapy trials: 3^322^–^324^
Results
Loss to followup 26% or higher or not reported | Medication-only trials: 0
| Psychotherapy trials: 1^325^
Differential loss to followup 15% or higher or not reported | Medication-only trials: 0
| Psychotherapy trials: 2^324,325^
Outcome measures not standard, reliable, or valid in all groups | Medication-only trials: 0
| Psychotherapy trials: 0
Discussion
Results do not support conclusions, taking possible biases and limitations into account | Medication-only trials: 0
| Psychotherapy trials: 0
Results not discussed within context of prior research | Medication-only trials: 0
| Psychotherapy trials: 0
External validity: population not representative of US population relevant to these treatments | Medication-only trials: 0
| Psychotherapy trials: 0
Funding/sponsorship not reported | Medication-only trial: 1^314^
| Psychotherapy trials: 0

### Participants

Of the 19 studies rated fair or good, 14 were conducted in the United States,^305^–^309,^ ^311,^ ^315^–^318,^ ^320,^ ^321,^ ^327,^ ^328^ and one each in Brazil,^312^ Germany,^319^ Italy,^330^ Switzerland,^310^and the United Kingdom.^326^ Five studies failed to report the age of participants; of the remainder, all focused on individuals 18 years of age or older (range, 18 to 65 years). With respect to sex, 1,132 individuals participated in fair or good clinical trials (984 women and 87 men; for 61 subjects, sex was not reported).

Six studies failed to report the race or ethnicity of participants. Of those that did, 775 participants were identified as white, 48 as nonwhite, 20 as African American, 12 as Hispanic American, and one as Native American. Drop-out rates from treatment trials appear in Table 21.

Table 21 Dropout rates for randomized controlled trials: binge eating disorder

Author | Total Enrollment, N | Total Dropouts, N (%) | G1 Treatment (% Dropout) | G2 Treatment (% Dropout) | G3 Treatment (% Dropout) | G4 Treatment (% Dropout)
Medication Trials
Arnold et al., 2002^305^ | 60 | 24 (40%) | Fluoxetine (57%) | Placebo (23%)
Hudson et al., 1998^306^ | 85 | 18 (21%) | Fluoxetine (NR) | Placebo (NR)
Pearlstein et al., 2003^307^ | 25 | 5 (20%) | Fluvoxamine (NR) | Placebo (NR)
McElroy et al., 2000^309^ | 34 | 8 (24%) | Sertaline (28%) | Placebo (19%)
McElroy et al., 2003^308^ | 38 | 7 (18%) | Citalopram (16%) | Placebo (21%)
Laederach-Hoffman et al., 1999^310^ | 31 | 2 (7%) | Imipramine (7%) | Placebo (6%)
McElroy et al., 2003^311^ | 61 | 26 (43%) | Topiramate (47%) | Placebo (39%)
Appolinario et al., 2003^312^ | 60 | 12 (20%) | Sibutramine (23%) | Placebo (17%)
Medication plus Behavioral Intervention Trials
Grilo, Masheb, and Wilson, 2005^315^ | 108 | 22 (20%) | Placebo (15%) | Fluoxetine (22%) | CBT + placebo (21%) | CBT + fluoxetine (23%)
Agras et al., 1994^316^ | 109 | 24 (22%) | Weight loss therapy (27%) | CBT + Weight loss (17%) | CBT + Weight loss + desipramine (23%)
Grilo, Masheb, and Salant, 2005^317^ | 50 | 11 (22%) | Orlistat + CBT (24%) | Placebo + CBT (20%)
Behavioral Interventions
Gorin, Le Grange, and Stone, 2003^320^ | 94 | 32(34%) | Standard CBT (NR) | Standard CBT with spouse involvement (NR) | Waiting list control (NR)
Hilbert and Tuschen-Caffier, 2004^319^ | 28 | 4 (14%) | CBT with a body exposure component (14%) | CBT with a cognitive restructuring component focused on body image (14%)
Wilfley et al., 2002^318^ | 162 | 29 (18%) | CBT (20%) | Interpersonal psychotherapy (16%)
Telch, Agras, and Linehan, 2001^321^ | 44 | 10 (23%) | Dialectical behavior therapy (18%) | Waiting list control (27%)
Self-help
Carter and Fairburn, 1998^326^ | 72 | 9 (12%) | Guided self-help (24%) | Pure self-help (0%) | Waiting list control (4%)
Peterson et al., 1998^328^ | 50 (to active treatment) | 8 (16%) | Therapist-led (13%) | Partial self-help (11%) | Structured self-help (27%) | Waiting list control (0%)
Peterson et al., 2001^327^ | 51 | 7 (14%) | Therapist-led (NR) | Partial self-help (NR) | Structured self-help (NR)
Riva et al., 2002^330^ | 20 | 0 (0%) | Virtual Reality (0%) | Psych-nutritional group (0%)

CBT, cognitive behavioral therapy; G, group; N, number; NR, not reported.

## Key Question 1: Treatment Efficacy

### Medication-only Trials

We report eight randomized controlled double-blind trials of medications (Table 22).^305^–^312^ A total of 413 individuals enrolled in medication-only trials. Based on studies that reported sex (all except one study),^311^ 322 women and 25 men participated in medication-only BED trials. The number of participants in the medication trials ranged from 20 to 85. The age of participants ranged from 18 to 60 years. Five trials reported the race of participants: 234 individuals were reported to be white and 29 nonwhite. Six trials were conducted in the United States,^305^–^309,^ ^311^ one in Brazil,^312^ and one in Switzerland.^310^

Table 22 Results from medication trials: binge eating disorder

Source, Treatment, Setting, and Quality Score | Major Outcome Measures | Significant Change Over Time Within Groups | Significant Differences Between Groups at Endpoint | Significant Differences Between Groups in Change Over Time
Arnold et al., 2002^305^ | Eating:; - Abstinence; - Binge eating | No statistics reported | Fluoxetine associated with lower illness severity and depressed mood, and less weight gain. | Fluoxetine superior in reducing binge frequency, illness severity, and depressed mood, and in controlling weight and BMI gain over 6 weeks.
Fluoxetine vs. placebo | Biomarker:; - BMI; - Weight
Outpatient | Psych:; - CGI; - HAM-D
Good
Hudson et al., 1998^306^ | Eating:; - Binge eating; - Remission | No statistics reported | No statistics reported | Fluvoxamine superior in reducing binge frequency, clinical severity, and BMI over 9 weeks.
Fluvoxamine vs. placebo | Biomarker:; - BMI
Outpatient | Psych:; - CGI; - HDRS
Fair
Pearlstein et al., 2003^307^ | Eating:; - Binge eating; - EDE | No statistics reported | No statistics reported | No differences on any measures
Fluvoxamine vs. placebo | Biomarker:; - Weight
Outpatient | Psych:; - BDI; - HAM-D; - SCL-90
Good
McElroy et al., 2003^311^ | Eating:; - Binge eating; - YBOCS-BE | No statistics reported | No statistics reported. | Topiramate superior in reducing binge frequency, illness severity, eating-related obsessions, compulsions, BMI, and weight over 14 weeks.
Topiramate vs. placebo | Biomarker:; - BMI; - Weight
Outpatient | Psych:; - CGI; - HDRS
Fair
McElroy et al., 2003^308^ | Eating:; - Binge eating; - YBOCS-BE | No statistics reported | Citalopram asscociated with greater reduction in frequency of binge days, BMI, and weight. | Citalopram superior to placebo in the rate of reduction in frequency of binges, illness severity, binge eating related obsessions and compulsions, and weight over 6 weeks.
Citalopram vs. placebo | Biomarker:; - BMI; - Weight
Outpatient | Psych:; - CGI; - HAM-D
Fair
Laederach-Hoffman et al., 1999^310^ | Eating:; - Binge eating | Imipramine decreased binge frequency and depressed mood over 8 weeks, and decreased depressed mood and weight at 32 week FU. | No statistics reported | Imipramine superior to placebo in decreasing binge frequency, depressed mood, and body weight over 8 weeks of active tx, and 32-week FU.
Imipramine vs. placebo (with dietary and psychological counseling | Biomarker:; - BMI; - Waist-hip ratio weight
Outpatient | Psych:; - HAM-D; - SDS
Fair
McElroy, Casuto et al., 2000^309^ | Eating:; - Binge eating | No statistics reported | No statistics reported | Sertraline superior to placebo in reducing binge frequency, illness severity, and BMI, and in increasing global improvement over 6 weeks.
Sertraline vs. placebo | Biomarker:; - BMI
Outpatient | Psych:; - CGI; - HDRS
Good
Appolinario et al., 2003^312^ | Eating:; - BES; - Binge eating; - Remission | No statistics reported | Sibutramine associated with less depressed mood. | Sibutramine superior to placebo in reducing binge frequency and severity.
Sibutramine hydrochloride vs. placebo | Biomarker:; - Weight | | | Difference in weight at end of treatment with weight decreasing over treatment period in the sibutramine group but increasing in the placebo group.
Outpatient | Psych:; - BDI
Good

BDI, Beck Depression Inventory; BES, Binge Eating Scale; BMI, body mass index; CGI, Clinical Global Impressions; EDE, Eating Disorders Examination; FU, followup; HAM-D, Hamilton Depression Inventory; HDRS, Hamilton Depression Rating Scale; Psych, psychiatric and psychological; SCL-90, (Hopkins) Symptom Check List; SDS, Self-rating Depression Scale; vs., versus; YBOCS-BE, Yale-Brown Obsessive Compulsive Scale (modified for binge eating).

Second-generation antidepressants. Fluoxetine. One trial compared fluoxetine (average dose 71.3 mg/day) with placebo in 60 individuals meeting the Diagnostic and Statistical Manual for Psychiatric Disorders-Version IV (DSM IV) criteria for BED with three or more binges per week for 6 months and higher than 85 percent ideal body weight (IBW) in a 6-week flexible dose trial.^305^ Fluoxetine significantly decreased binges per week, severity of illness, and clinician-rated depression scores. It was associated with less weight gain than the placebo, although both groups gained weight during treatment. The investigators failed to report abstinence rates and long-term followup. Dropout was 57 percent in the fluoxetine group and 23 percent in the placebo group. Any inferences made from this study must be made with extreme caution because of the very high and differential attrition rate.

Other second-generation antidepressants. A 9-week trial compared fluvoxamine (50–300 mg/day) with placebo in 85 patients with BED, at least three binge eating episodes per week for 6 months, and higher than 85 percent of the midpoint of their ideal weight for height. Using intention-to-treat analyses, the investigators showed that patients on fluvoxamine had a significantly greater rate of reduction in binge frequency than those on placebo; however, the remission rate did not differ between groups.^306^ The rate of improvement in severity of illness but not in depression was greater in the fluvoxamine group than in the placebo group. Fluvoxamine led to a greater rate of reduction of body mass index (BMI); however, BMI at endpoint was not reported so the clinical significance of the weight change could not be evaluated. The investigators failed to report long-term followup. Overall dropout was 21 percent.

In a 12-week trial of fluvoxamine (average dose 239 mg/day) versus placebo in 20 patients with DSM-IV BED, investigators observed no differences between fluvoxamine and placebo on binge eating frequency, although both groups combined showed decreases in binge frequency at the end of treatment.^307^ Both groups combined had significant decreases in shape and weight concerns with no differences between them. Self-reported depression decreased similarly for both. Neither group showed significant weight change with treatment. The investigators failed to report long-term followup. Overall dropout was 20 percent.

McElroy et al. compared 6 weeks of sertraline (mean dose 187 mg/day) with placebo in 34 individuals with DSM-IV BED, at least three binge episodes per week for 6 months, and greater than 85 percent of IBW.^309^ Sertraline led to greater reduction in binges per week but not with complete remission when rated categorically. It was also associated with increased reduction in severity of illness but not with depression scores. The drug also led to greater reductions in weight; however, the investigators failed to report BMI at endpoint so the clinical significance of the weight change is unclear. The investigators failed to present long-term follow-up data. Dropout was 28 percent in the sertraline group and 19 percent in the placebo group.

In a 6-week trial of citalopram (40–60 mg/day) versus placebo in 38 individuals with BED, with three or more binge episodes per week for 6 months and more than 85 percent of IBW, the active drug led to a significantly greater rate of decrease of binge eating and binge eating days; however, the percentage of individuals remitted when measured categorically did not differ significantly.^308^ The citalopram group showed greater reductions in clinician-rated obsession and compulsion scores and in severity of illness and depression scores. The BMI rate of change was significantly greater in the citalopram group; patients lost on average 2.7 kg and those on placebo gained 5.2 kg during treatment. Although the rate of change data suggested more rapid response in the citalopram group, differences between the groups over time were not significant for the core outcome variables of binges per week or severity of illness. Dropout was 16 percent in the citalopram group and 21 percent in the placebo group.

Tricyclic antidepressants. Laederach-Hoffman et al. augmented standard bi-weekly diet counseling and psychological support with either impiramine (25 mg three times a day) or placebo in 31 individuals with DSM-IV BED and BMI greater than 27.5.^310^ Significantly greater reductions in binge eating episodes and Hamilton Depression Rating Scale (HAM-D) scores occurred in the impiramine group at 8 and 32 weeks. Body weight was significantly reduced in the imipramine group at 8 and 32 weeks (mean reduction of 2.1 kg at 8 weeks and 5.0 kg at 32 weeks); the placebo group gained weight. Abstinence rates were not reported. Low doses of imipramine when delivered in the context of psychological support and diet counseling led to maintenance of decreased binge eating, depression, and weight. Dropout was between 6 percent and 7 percent in both groups.

Anticonvulsants. One 14-week trial compared topiramate (average dose 212 mg/day) with placebo in 61 individuals with BED, BMI greater than 30, and a score greater than 15 on the Yale-Brown Obsessive Compulsive Scale for Binge Eating (YBOCS-BE).^311^ Patients receiving topiramate experienced a significantly greater rate of change and a significantly greater percentage reduction in binge episodes, binge days per week, and YBOC-BE. Severity of illness, but not depression scores, showed greater improvement in the topiramate group. Topiramate led to significantly greater and clinically meaningful weight loss (5.9 kg) than placebo (1.2 kg). No follow-up data were provided. The investigators failed to report abstinence rates or endpoint values, so estimating the magnitude of clinical significance of differences is difficult. Dropout was 47 percent in the topiramate group and 39 percent in the placebo group.

Sibutramine. A 12-week comparison of sibutramine (15 mg/day) with placebo in 60 individuals with DSM-IV BED and a Binge Eating Scale (BES) score of greater than or equal to 17 indicated that sibutramine produced significant decreases in binge days per week and BES scores than placebo.^312^ Sibitramine was also associated with a significant decrease in self-reported depression scores over the course of treatment. At week 12, the sibutramine group had lost on average 7.4 kg whereas the placebo group gained weight (a significant difference). The authors did not report abstinence rates or provide long-term follow-up data. Dropout was 23 percent in the sibutramine group and 17 percent in the placebo group.

Summary of medication-only trials. Treating BED in overweight individuals has two critical outcomes—decrease in binge eating and decrease in weight. Although not all BED studies explicitly sampled on the basis of weight, all focused on overweight individuals. Four selective serotonin reuptake inhibitors (SSRIs)—one serotonin, dopamine, and norepinephrine uptake inhibitor; one tricyclic antidepressant; one anticonvulsant; and one appetite suppressant—have been studied in BED. In short-term trials, SSRIs appear to lead to greater rates of reduction in target eating, psychiatric and weight symptoms, and severity of illness. However, in the absence of clear endpoint data, and in the absence of data regarding abstinence from binge eating, we cannot judge the magnitude of the clinical impact of these interventions. Moreover, lacking follow-up data after drug discontinuation, we do not know whether observed changes in binge eating, depression, and weight persist.

Low-dose imipramine as an augmentation strategy to standard dietary counseling and psychological support is associated with decreases in binge eating and weight that persist after discontinuation of the medication. This finding suggests a potentially promising pairing worth further investigation.

Both sibutramine and topiramate yielded promising results in terms of weight reduction for patients with BED: clinically significant reductions in BMI over the short term. The authors of these reports did not supply remission rates. Additional research is required to track patients after drug discontinuation to determine whether observed changes in eating behavior and weight persist.

Several studies reported rate of change of symptoms rather than actual differences in groups in change over time including endpoint values. Although rate of change is of interest, endpoint measures, including consistently defined abstinence rates, are critical to evaluate the clinical status of participants at the end of treatment.

Overall, drop-out rates were between 16 percent and 57 percent in the medication trials for BED. The high placebo response in BED is noteworthy.

### Medication Plus Behavioral Intervention Trials

We present three trials of medications plus psychotherapy in Table 23.^315^–^317^ The total number of individuals enrolled in these combination trials was 267 (237 women and 30 men).

Table 23 Results from medication plus behavioral intervention trials: binge eating disorder

Source, Treatment, Setting, and Quality Score | Major Outcome Measures | Significant Change Over Time Within Groups | Significant Differences Between Groups at Endpoint | Significant Differences Between Groups in Change Over Time
Grilo, Masheb, Salant, 2005^317^ | Eating:; - EDE; - Remission | No statistics reported | Greater percentage of CBT + orlistat group remitted and achieved at least 5 percent weight loss over 12 weeks. Group difference in weight loss maintained at 2-month FU | CBT + orlistat superior in total weight loss and in percent weight loss to post-tx over 12 weeks.
CBT + orlistat vs. CBT + placebo | Biomarker:; - Weight loss
Outpatient | Psych:; - BDI
Good
Agras et al., 1994^316^ | Eating:; - Binge eating; - TFEQ | No statistics reported | No statistics reported | CBT plus weight loss (with or without desipramine) superior to weight loss alone in reducing binge frequency over 12 weeks.
Weight loss therapy vs. CBT+weight loss therapy vs. CBT+weight loss therapy + desipramine | Biomarker:; - Weight | | | Significant difference between groups at 12 wks in change in weight over time with weight decreasing in weight loss group and increasing in CBT groups. By 3 month FU, CBT plus desipramine superior to CBT without desipramine in reducing weight.
Outpatient | Psych:; - BDI
Fair
Grilo, Masheb, Wilson, 2005^315^ | Eating:; - Binge eating; - BSQ; - EDE; - Remission; - TFEQ | No statistics reported | No statistics reported | CBT groups superior to placebo and fluoxetine alone in decreasing binge frequency, eating and shape concerns, global eating score, disinhibition, and rate of remission.
Fluoxetine vs. placebo vs. CBT + placebo vs. CBT + fluoxetine | Biomarker:; - BMI | | | CBT + fluoxetine superior to placebo alone and fluoxetine alone in decreasing weight concerns and hunger; superior to fluoxetine alone in reducing depressed mood and dietary restraint; superior to placebo in decreasing body dissatisfaction.
Outpatient | Psych:; - BDI | | | CBT + placebo superior to placebo alone and fluoxetine alone in decreasing depressed mood; superior to fluoxetine alone in decreasing dietary restraint, weight concerns, and body dissatisfaction.
Good

BDI, Beck Depression Inventory; BMI, Body mass index; BSQ, Body Shape Questionnaire; CBT, Cognitive Behavioral Therapy; EDE, Eating Disorders Examination; FU, followup; Psych, psychiatric and psychological; TFEQ, Three Factor Eating Questionnaire; Tx, treatment, vs., versus.

The number of participants in these combination trials ranged from 50 to 109. Age ranged from 21 to 65 years. Of these three trials, two reported the race or ethnicity of participants: 140 individuals were reported as white, 12 as African American, and six as Hispanic American.^315,^ ^317^ The United States was the site of all three trials.

Second-generation antidepressants and CBT. Grilo et al. compared fluoxetine (60 mg/day) with placebo, both with and without CBT, in a 16-week trial.^315^ Treatment groups receiving CBT reported greater reductions in binge episodes, eating and shape concerns, disinhibition, and depression and greater remission rates than did the medication-only or placebo groups. Weight loss did not differ across groups; the authors did not report within-group weight loss over time. Dropout between groups was comparable (between 15 percent and 23 percent).

Tricyclic antidepressants and CBT. Agras et al. compared the effects of weight-loss treatment, CBT, and desipramine in 109 individuals with DSM IV BED. They randomly allocated participants to 9 months of weight-loss-only therapy, 3 months of CBT followed by 6 months of weight-loss therapy, or 3 months of CBT followed by 6 months of weight-loss therapy and desipramine (300 mg/day).^316^ Groups receiving CBT showed significant reduction in binge eating at 12 weeks but not at any later follow-up point. Likewise, any observed differences on self-report measures of eating pathology were no longer significantly different at 36 weeks. Changes in depression scores did not differ across groups. Initial weight loss was greater in the weight-loss therapy group. At 3-month followup, the greatest weight loss was seen in the group including CBT and desipramine (average reduction of 4.8 kg from baseline). Dropout from acute treatment was comparable across groups: from 27 percent in the weight-loss therapy group to 17 percent in the CBT plus weight-loss therapy group.

Orlistat and CBT. In a 12-week trial of orlistat (120 mg three times/day) with CBT and placebo with CBT in 50 individuals with DSM-IV BED and BMI > 30, the orlistat group had greater remission rates at the end of treatment but not at 2-month followup.^317^ The authors reported no differences in any other eating-related or depression measures. Individuals in the orlistat group experienced greater initial weight loss (-3.5 kg) than those in the placebo group (-1.6 kg), but that loss was not maintained at followup; at followup, however, the orlistat group was more likely to have achieved a weight loss of 5 percent or more. Dropout (about 20 percent) was comparable between groups.

Summary of medication plus psychotherapy trials. Adding CBT conferred benefit on remission rate, but not weight loss, over fluoxetine alone or placebo alone in one trial.^315^ Adding CBT to orlistat was associated with a greater decrease in weight during treatment, although this does not appear to be maintained at followup.^317^ In one trial, adding desipramine to CBT and weight loss therapy led to greater maintenance of weight loss over time.^316^ Combining medication and CBT may improve both binge eating and weight loss, although sufficient trialshave not been done to determine definitively which medications are best at producing and maintaining weight loss. Moreover, the optimal duration of medication treatment for sustained reductions in binge eating and maintenance of weight loss has not yet been addressed empirically.

### Behavioral Intervention Trials

We identified eight behavioral intervention-only trials (Table 24),^318^–^325^ three trials of self-help (Table 25),^326^–^328^ and one trial each of exercise and virtual reality (Table 26).^329,^ ^330^

Table 24 Results from behavioral intervention trials, no medication: binge eating disorder

Source, Treatment, Setting, and Quality Score | Major Outcome Measures | Significant Change Over Time Within Groups | Significant Differences Between Groups at Endpoint | Significant Differences Between Groups in Change Over Time
Gorin et al., 2003^320^ | Eating:; - Abstinence; - Binge eating; - TFEQ | No statistics reported | Higher percent abstinent in CBT groups compared to waiting list. | CBT (with and without spouse involvement) superior to waiting list in decreasing number of binge days, disinhibition, hunger, depressed mood, and BMI over 12 weeks.
Group-based CBT vs. CBT with spouse involvement vs. waiting list | Biomarker:; - BDI
Outpatient | Psych:; - BMI
Fair
Hilbert and Tuschen-Caffier, 2004^319^ | Eating:; - Binge eating; - Body Satisfaction; - EDE; - Negative automatic thoughts; - Recovery | Binge frequency, depressed mood, shape and weight concerns, body dissatisfaction, and restraint decreased in both groups over time. | No differences in percent recovered. | No differences on any measures.
CBT+exposure vs. CBT+cognitive interventions for image disturbance | Biomarker:; - BMI
Outpatient | Psych:; - BDI
Fair
Wilfley et al., 2002^318^ | Eating:; - Abstinence; - Binge eating; - EDE | Both interventions associated with decreased number of binge days and eating restraint at post-tx, 4- and 8-month FU. | Less restraint in CBT at post-tx and 4-month FU. | CBT superior in decreasing eating restraint at post-tx and 4, 8, and 12 month FU.
CBT vs. IPT | Biomarker:; - BMI | Both tx associated with decreased GSI total scores; shape, weight, and eating concerns, restraint, and depressed mood at post-tx.
Outpatient | Psych:; - GSI; - SCL-90
Good
Telch et al., 2001^321^ | Eating:; - BES; - Binge eating; - EDE; - EES | No statistics reported | No statistics reported | DBT superior to waiting list control in decreasing number of binge episodes and binge days, binge severity, and weight, shape, and eating concerns.
DBT vs. waiting list | Biomarker:; - Weight
Outpatient | Psych:; - BDI; - PANAS; - RSE
Fair

BDI, Beck Depression Inventory; BES, Binge Eating Scale; BMI, body mass index; CBT, Cognitive Behavioral Therapy; DBT, Dialectical Behavior Therapy; EDE, Eating Disorders Examination; EES, Emotional Eating Scale; FU, followup; GSI, General Severity Index (derived from BSI); PANAS, Positive and Negative Affect Schedule; Psych, psychiatric and psychological; RSE, Rosenberg Self-Esteem Scale; SCL-90, (Hopkins) Symptom Check ListTFEQ, Three Factor Eating Questionnaire; Tx, treatment, vs. versus.

Table 25 Results from self-help trials, no medication: binge eating disorder

Source, Treatment, Setting, and Quality Score | Major Outcome Measures | Significant Change Over Time Within Groups | Significant Differences Between Groups at Endpoint | Significant Differences Between Groups in Change Over Time
Carter and Fairburn, 1998^326^ | Eating:; - Abstinence; - Binge eating; - EDE | Both self-help groups decreased binge eating, GSI, and EDE global at 12-week post-tx. | Both self-help groups associated with higher abstinence rates, less binge eating, and lower GSI, EDE global and restraint scores, compared to waiting list at post-tx. | Guided self-help superior to non-guided self-help and waiting list in reducing eating restraint over 12 weeks.
Guided self-help vs. non-guided self-help vs. waiting list | Biomarker:; - BMI; - Weight | Guided self-help only decreased eating restraint at post-tx. | Guided self-help associated with less restraint and binge eating at 3 month FU and with less binge eating at 6 month FU compared to non-guided self-help.
Outpatient | Psych:; - BSI; - GSI
Good
Peterson et al., 1998^328^ | Eating:; - Abstinence; - BES; - Binge eating; - BSQ; - Eating Behavior-IV; - TFEQ | No statistics reported | Abstinence rates for binge eating higher in each of the CBT groups compared to waiting list | CBT groups superior to waiting list in decreasing objective and total binge episodes/week, hours spent binge eating/week, binge severity, disinhibition, and hunger over 8 weeks.
Therapist-led group CBT vs. partial self-help group CBT vs. structured self-help group CBT vs. waiting list | Biomarker:; - BMI
Outpatient | Psych:; - HDRS; - RSE
Fair
Peterson et al., 2001^327^ | Eating:; - Abstinence; - Binge eating; - BSQ; - TFEQ | No statistics reported | Abstinence from total binge episodes higher in structured self-help group versus therapist-led self-help and partial self-help groups. | No differences on any measures
Therapist-led group CBT vs. partial self-help group CBT vs. structured self-help group CBT | Biomarker:; - BMI
Outpatient | Psych:; - BDI; - HDRS
Fair

BDI, Beck Depression Inventory; BES, Binge Eating Scale; BMI, Body mass index; BSI, Brief Symptom Inventory; BSQ, Body Shape Questionnaire; CBT, Cognitive Behavioral Therapy; EDE, Eating Disorders Examination; FU, followup; GSI, General Severity Index (derived from BSI); HDRS, Hamilton Depression Rating Scale; Psych, psychiatric and psychological; RSE, Rosenberg Self-Esteem Scale; TFEQ, Three Factor Eating Questionnaire; Tx, treatment, vs., versus.

Table 26 Results from other trials: binge eating disorder

Source, Treatment, Setting, and Quality Score | Major Outcome Measures | Significant Change Over Time Within Groups | Significant Differences Between Groups at Endpoint | Significant Differences Between Groups in Change Over Time
Riva et al., 2002 | Eating:; - Abstinence; - BIAQ; - BSS; - CDRS; - DIET; - FRS; - WELSQ | Virtual reality tx associated with increased ideal body score and WELSQ total score, and decreased state anxiety. | No statistics reported | Virtual reality tx superior to psycho-nutritional tx in increasing WELSQ total score and in decreasing state anxiety and overeating.
Virtual reality-based tx for body image vs. CBT-based psycho-nutritional group therapy | Psych:; - STAI
Inpatient
Fair

BMI, Body mass index; BIAQ, Body Image Avoidance Questionnaire; BSS, Body Satisfaction Scale; CBT, cognitive behavioral therapy; CDRS, Contour Drawing Rating Scale; DIET, Dieter's Inventory of Eating Temptations; FRS, Figure Rating Scale; Psych, psychiatric and psychological; STAI, Spielberger State-Trait Anxiety Inventory; Tx, treatment; WELSQ, Weight Efficacy Life-style Questionnaire.

In behavioral intervention trials, CBT tailored for BED was the most commonly tested therapeutic approach; one study used DBT. The total number of individuals enrolled in psychotherapy, self-help, exercise, and virtual reality trials was 481 (449 women and 32 men). Of the eight trials identified, participants ranged in age from 18 to 65 years. Six trials reported the race and ethnicity of participants: in all, they involved 401 persons identified as white, 19 individuals as nonwhite, eight as African American or Afro-Caribbean, six as Hispanic American, one as Native American, and one as Asian. In no instance were results analyzed specifically by race or ethnic group. Of the eight trials, five were conducted in the United States and one each in Germany, the United Kingdom, and Italy.

Behavioral intervention trials for binge eating disorder. CBT. A 12-week trial of standard CBT tailored for BED compared with CBT and spousal involvement and with a waiting list control group in 94 individuals with a BMI of 25 or more showed that both active CBT groups had significant reductions in days binged, BMI, disinhibition, hunger, depression, and self-esteem than the controls and were more likely to be abstinent from binge eating at the end of treatment. Adding spousal involvement did not produce significantly greater improvements than standard CBT.^320^ Both CBT groups had significantly lower depression scores and BMI, but they did not differ from each other. The average BMI decrease from baseline to followup was 0.11 for CBT and 0.77 for CBT with spousal involvement, suggesting that CBT alone, with or without a spouse participating, did not yield substantial weight change. Overall, dropout was 34 percent.

Hilbert et al. studied 5 months of group CBT with body exposure treatment and group CBT with cognitive restructuring of negative body cognitions in 28 women with BED, using a broad inclusion criterion of at least one binge per week.^319^ Both groups showed decreases in binge eating, psychological aspects of binge eating, self-report binge eating scores, and decreases in self-report depression, but differences between groups were not statistically significant. Neither group experienced significant weight loss. Dropout was 14 percent in each group.

Looking at the efficacy of group psychotherapy, Wilfley et al. compared group CBT with group IPT in 20 sessions with 3 additional individual sessions in 162 individuals with BED and BMI levels between 27 and 48.^318^ Both therapies led to significant decreases in the number of days binged at the end of treatment and at 4-month followup. CBT led to greater improvements in Eating Disorders Examination Restraint scores at all time points. At 12 months, the groups did not differ in abstinence (CBT, 72 percent; IPT, 70 percent), severity of illness, or depression; both treatments led to significant reductions in these parameters. No participants in either group experienced reductions in BMI across treatment or follow-up periods. Dropout was 20 percent in CBT and 16 percent in IPT.

Dialectical behavioral therapy. Twenty weeks of DBT led to greater reduction in binge days, binge episodes, weight concern, shape concern, and eating concern than did being in a waiting list control group in 44 women with DSM-IV BED.^321^ Depression and anxiety scores did not differ. The authors did not report whether DBT was associated with significant change in weight, although no differences in weight loss emerged between groups during treatment. Dropout was 18 percent in the DBT group and 55 percent in the waiting list group.

Self-help trials. Carter and Fairburn compared guided self-help using a book^302^ combined with six to eight sessions with a facilitator with self-help-only using the same book in the absence of a facilitator and with waiting list controls in 72 women with BED with weekly binges.^326^ Both self-help approaches were more efficacious than the control arm in reducing the mean number of binge days and improving abstinence and cessation rates and EDE scores. At the end of treatment, both self-help groups showed significantly greater reductions in clinical severity than the control group. No group reported significant weight loss at any point. Comparisons of the two self-help groups yielded no differences in eating, depression, or BMI measures at any follow-up point. Dropout was 24 percent from guided self-help and 4 percent from the control group; self-help-only had no dropouts.

In a four-group comparison, Peterson et al. compared therapist-led self-help, partial self-help, structured self-help, and waiting list controls in 61 individuals with DSM IV BED.^328^ In therapist-led self-help, a doctoral-level therapist led both the psychoeducational component and group discussion; in the partial self-help group, participants viewed a 30-minute psychoeducational videotape and then participated in a therapist-led discussion; and in the structured self-help group, subjects viewed the 30-minute psychoeducational videotape and then led their own 30-minute discussion. All self-help groups performed better than controls on objective binges, total binges, hours spent bingeing, and self-reported eating attitudes. For abstinence rates, all self-help groups (68 percent to 87 percent) were better than controls (12.5 percent). The groups did not differ in depression scores or BMI changes. Dropout was higher in the structured self-help group (27 percent) than in the therapist-led (13 percent) and partial (11 percent) self-help groups.

The second report on this sample compared therapist-led self-help, partial self-help, and structured self-help in 51 individuals with DSM-IV BED.^327^ All three approaches led to significant decreases in objective binges, hours spent bingeing, and body dissatisfaction. Structured self-help led to significantly greater abstinence at the end of treatment but not at followup. Depression scores decreased over time but not differentially across groups. BMI changes did not differ across groups; the authors did not report whether significant decreases occurred within groups, but the numerical changes appeared to be minimal. Dropout was not reported.

Additional interventions for binge eating disorder. In an inpatient trial, Riva et al. compared virtual reality therapy to psychonutritional control in 20 women with DSM IV BED.^330^ Virtual reality therapy uses interactive three-dimensional visualization, a head-mounted display, and data gloves to modify body image perceptions. In this very small study with a large number of outcome measures, the investigators compared seven sessions of virtual reality plus a low-calorie diet and physical training with psychonutritional CBT, a low-calorie diet, and physical training. Virtual reality showed significant improvements in weight efficacy and diet scores. Abstinence did not differ significantly between groups and was 100 percent in each, most likely secondary to intensive inpatient treatment. Dropout was not reported.

Summary of behavioral interventions for binge eating disorder. Investigators most frequently chose to study CBT. However, no basic trial comparing individually administered CBT with waiting list, treatment as usual, or a second therapy was rated as fair or good.

The three fair- or good-rated trials that incorporated CBT provided treatment for between 12 weeks and 5 months. Collectively, these trials indicated two main findings. First, CBT is effective in reducing either the number of binge days or the actual number of reported binge episodes. Second, in comparison to waiting list controls, it leads to greater rates of abstinence when administered either individually or in group format, and this abstinence persists for up to 4 months post treatment. CBT also improves the psychological aspects of BED such as ratings of restraint, hunger, and disinhibition. Results are mixed as to whether CBT improves self-rated depression in this population. In all three studies CBT did not lead to decreases in weight. Whether the successful treatment of BED with CBT is associated with less weight gain (as opposed to actual weight loss) over time in individuals with BED has not yet been adequately addressed. Similarly, DBT (one trial) is associated with decreases in binge eating and psychological aspects of the disorder but not with definitive change in depression or anxiety or apparent weight loss.

Although CBT and DBT decrease binge eating and related psychological features of the disorder, they have no observable impact on the important outcome variable of weight loss. This is a somewhat puzzling finding as one would expect decreases in binge eating to be associated with weight loss. The reason for no weight loss is unclear. It is possible that calories previously consumed as binges may be distributed over nonbinge meals; or, how patients label binges and nonbinge meals may change with treatment. In any case, despite reported changes in eating patterns, little demonstrable weight change is achieved.

Self-help (three trials) is efficacious in decreasing binge days, binge eating episodes, and psychological features associated with BED. It also leads to greater abstinence from binge eating when compared to individuals randomized to a waiting list control condition; short-term abstinence rates approximate those seen in face-to-face psychotherapy trials. No self-help trials led to significant decreases in self-rated depression scores or weight in comparison to waiting list controls. Virtual reality therapy must be viewed as experimental; the intensive inpatient treatment associated with this trial invariably affects the perfect abstinence rates observed in both treatment groups. Observing any added efficacy of virtual reality therapy is difficult at best.

Overall dropout rates in behavioral interventions for BED were between 11 percent and 27 percent in active treatment groups.

## Key Question 2: Harms of Treatment for Binge Eating Disorder

Table 27 presents adverse events associated with BED treatments. For the trials using second-generation antidepressants, we refer to a recently completed report on the comparative effectiveness and tolerability of second-generation antidepressants (see Chapter 3).^243^ In the BED clinical trials, the commonly reported side effects in trials involving fluoxetine were sedation, dry mouth, headache, nausea, insomnia, diarrhea, fatigue, increased urinary frequency, and sexual dysfunction. With fluvoxamine adverse events that occurred significantly more frequently than with placebo included insomnia, nausea, and abnormal dreams. Additional commonly reported adverse events included headache, asthenia, depression, dizziness, somnolence, dry mouth, nervousness, and decreased libido. Patients treated with sertraline experienced insomnia at a significantly greater rate than those receiving placebo; citalopram was associated with more reports of sweating and fatigue than placebo. For tricyclic antidepressants, 24 percent of individuals treated with desipramine discontinued treatment because of side effects. For imipramine, only anticholinergic effects (constipation, dry mouth, blurred vision) were reported more frequently in active drug than placebo participants. In the topiramate trial, six of 30 patients dropped out because of adverse events including headache, parasthesias, and amenorrhea. Individuals treated with sibutramine experienced significantly more constipation than those treated with placebo. Gastrointestinal events were reported more often in individuals receiving orlistat than in those receiving placebo.

Table 27 Adverse events reported: binge eating disorder trials

Intervention | Adverse Events Reported
Medication Trials^*^†
Fluoxetine versus placebo^305^ | Fluoxetine group: sedation (5), dry mouth (11), headache (9), nausea (7), insomnia (7), diarrhea (6), fatigue (6), increased urinary frequency (4), sexual dysfunction (4).
| Both groups: hand and foot swelling, palpitations, and apathy; (P = NS)
Fluvoxamine versus placebo^306^ | Fluvoxamine group: insomnia, headache, nausea, asthenia, depression, dizziness, somnolence, abnormal dreams, dry mouth, nervousness, and decreased libido. Insomnia, nausea, and abnormal dreams significantly more common in fluvoxamine than placebo.
Fluvoxamine versus placebo^307^ | Fluvoxamine group: sedation (8); nausea (4); dry mouth (4); decreased libido (3)
| Placebo group: sedation (3); nausea (1); dry mouth (3); decreased libido (0) (P = NR)
Sertraline versus placebo^309^ | Sertraline group: insomnia (7)
| Placebo group: insomnia (1) (P = 0.04)
Citalopram versus placebo^308^ | Citalopram group: sweating (9) (P = 0.008); fatigue (5) (P = 0.05)
| Placebo group: sweating (1); fatigue (0)
| Also reported: dry mouth, headache, diarrhea, nausea, sedation, insomnia, sexual dysfunction
Imipramine versus placebo^310^ | Imipramine group: skin eruptions and an aversion to tablet intake (1) anticholinergic effects (7)
| Placebo group: hunger, sweating, palpitations, arrhythmia, and general malaise (1); anticholinergic effects (3); (P < 0.05)
Topiramate versus placebo311 | Topiramate group: headache, paresthesias and amenorrhea
| Placebo: leg cramps, sedation and testicular soreness
Sibutramine hydrochloride versus placebo^312^ | Sibutramine: dry mouth (22); headache (6); constipation (7)
| Placebo: dry mouth (3); headache (14); constipation (0) (P < 0.01)
| All other adverse events did not differ significantly (i.e., nausea, insomnia, sudoresis, lumbar pain, depressive mood, flu syndrome, malaise, others) (P = NS)
Medication Plus Behavioral Intervention
Placebo versus fluoxetine versus CBT + placebo versus CBT + fluoxetine^315^ | NR
Weight loss treatment versus CBT versus desipramine^316^ | 8 subjects discontinued desipramine because of side effects
Orlistat plus CBT versus Placebo plus CBT^317^ | Orlistat + CBT: significantly more gastrointestinal events
Behavioral Interventions
Standard CBT versus CBT with spouse involvement versus waiting list control^320^ | NR
CBT + exposure versus CBT + cognitive interventions for body image disturbances^319^ | NR
CBT versus IPT^318^ | NR
Dialectical behavioral therapy versus waiting list control^321^ | 3 women in DBT group were treated with either psychotherapy or medication for a major depressive episode.
Self-help
Guided self-help versus pure self-help versus waiting list control^326^ | NR
Therapist-led versus partial self-help versus structured self-help versus waiting list control^328^ | NR
Therapist-led versus partial self-help versus structured self-help^327^ | NR
Other Behavioral Interventions
Virtual reality based treatment versus psychonutritional control^330^ | No adverse events observed

CBT, cognitive behavioral therapy; IPT, interpersonal psychotherapy; NR, not reported; NS, not significant, vs., versus.

* If no numbers appear in parentheses, authors had only listed adverse events but not reported the number of cases.

† P values indicate differences between groups, they are reported when provided by author.

No direct adverse events were reported for any psychotherapy trials for BED. In the DBT trial, three individuals required treatment for depression during the follow-up period.

## Key Question 3: Factors Associated With Treatment Efficacy

Few studies reported on factors associated with efficacy of treatment in BED. Early abstinence from binge eating was associated with significantly greater weight loss in one study.^316^ In one self-help trial, higher initial self-esteem was associated with poorer outcome; however, the effect was small, accounting for 6 percent of the variance in outcome.^326^

## Key Question 4: Treatment Efficacy by Subgroups

The total number of individuals enrolled in the 12 drug or medication plus behavioral intervention trials was 680; of those, 55 were men. The age range of participants was reported in eight of the 12 studies; no study reported differential outcome by age. Of the seven studies that did report race or ethnicity, 374 participants were identified as white, 29 as nonwhite, 12 as African American, and six as Hispanic-American. Ten trials were conducted in the United States. No study analyzed results separately by sex, gender, race, or ethnicity. Based on these results, we conclude that no information exists about differential efficacy of pharmacotherapy interventions for BED by sex, age, gender, race, ethnicity, or cultural group.

The total number of individuals enrolled in psychotherapy, self-help, or other behavioral trials was 532; of those, 32 were men. Participants ranged in age from 18 to 64. No studies looked at BED treatment for children or adolescents. From the trials that reported race or ethnicity, participants included 450 whites, 19 nonwhites, eight African Americans or Afro-Caribbeans, six Hispanic-Americans, one Native American, and one Asian. In no instance did the investigators analyze results separately by race or ethnic group. No data exist regarding differential efficacy of psychotherapeutic treatment for BED by sex, age, gender, race, ethnicity, or cultural group.