# Results: Bulimia Nervosa

This chapter presents results of our literature search and our findings for the four key questions (KQs) that pertain to bulimia nervosa (BN), including the efficacy of various treatments or combinations of treatments (KQ 1), harms associated with the treatment or combination of treatments (KQ 2), factors associated with the efficacy of treatment (KQ 3), and whether the efficacy of treatment differs by sex, gender, age, race, ethnicity, or cultural groups (KQ 4).

We report specific details about the yields of the literature searches and characteristics of the studies. For each included study, detailed evidence tables appear in Appendix C ** We report first on medication trials (Evidence Table 5), then combined medication and behavioral interventions (Evidence Table 6), behavioral interventions (Evidence Table 7), self-help interventions (Evidence Table 8), and other interventions (Evidence Table 9). Within each evidence table, studies are listed alphabetically by author. Summary tables in this chapter present selected outcomes by type of intervention.

** Appendixes cited in this report are provided electronically athttp://www.ahrq.gov/downloads/pub/evidence/pdf/eatingdisorders/eatdis.pdf.

## Overview of Included Studies

We identified 47 studies reported in 58 publications addressing treatment efficacy for BN. Of these, 14 were medication-only trials.^244^–^257^ We rated two of these trials as good,^246,^ ^248^ 9 as fair,^244,^ ^247,^ ^249^–^255,^ ^257^ and three as poor.^245,^ ^256,^ ^258^ The drugs studied included second-generation antidepressants,^244,^ ^247^–^250,^ ^252,^ ^254,^ ^255^ tricyclic antidepressants,^257^ an anticonvulsant,^251,^ ^259^ monoamine-oxidase inhibitors (MAOIs),^253^ and a 5HT3 antagonist.^246^

Six trials combined medication with behavioral interventions.^260^–^265^ Three used second-generation antidepressants,^261,^ ^262,^ ^265^ one used a tricyclic antidepressant,^260^ and two used both a second-generation antidepressant and a tricyclic antidepressant sequentially.^263,^ ^264^ Of these, we rated two as good^264,^ ^265^ and four as fair.^260^–^263^

We identified 19 behavioral intervention psychotherapy studies published in 24 articles.^266^–^289^ We rated three psychotherapy intervention trials as good,^269,^ ^270,^ ^282^ 10 as fair,^266,^ ^273,^ ^274,^ ^276,^ ^278,^ ^280,^ ^281,^ ^283,^ ^287,^ ^288^ and six as poor.^275,^ ^279,^ ^284^–^286,^ ^289^ Of the 13 fair- and good-rated studies, 11 used some form of cognitive-behavioral therapy (CBT) in comparison to other interventions,^266,^ ^269,^ ^270,^ ^273,^ ^274,^ ^276,^ ^278,^ ^280,^ ^283,^ ^287,^ ^288^ one used dialectical behavior therapy (DBT),^282^ and one used nutritional management and stress management.^281^

We also identified five trials of various self-help methods.^290^–^294^ We rated four as fair^290^–^293^ and one as poor.^294^

Finally, we identified three studies of “other” interventions including active light,^295^ guided imagery,^296^ and crisis prevention.^297^ We rated all three studies as fair.

Of the 47 studies addressing treatment efficacy for BN, we rated 10 as poor. Studies with a quality rating of “poor” are not discussed below. Reasons that these studies received this rating are presented in Table 12. Although each study was not lacking in all areas, the most common concerns contributing to the low rating included a fatal flaw in the approach to randomization or the approach not being described, assessors not being blinded or their blinding status not being described, adverse events not being reported, outcomes not being reported using an intention-to-treat approach, the statistical analysis not including a power analysis or not stating whether one was conducted, and concerns in relation to the external validity of the findings (the study population was not representative of the US population or the information of provided was insufficient to determine representativeness).

Table 12 Reasons for poor quality ratings and number of trials with poor ratings: bulimia nervosa

Reasons Contributing to Poor Ratings | Types of Intervention, Number of Times Flaw Was Detected, and Citations
Research Aims
Hypothesis not clearly described | Medication-only trials: 0
| Behavioral intervention and self-help trials: 0
Study Population
Characteristics not clearly described | Medication-only trials: 0
| Behavioral intervention and self-help trials: 1^289^
No specific inclusion or exclusion criteria | Medication-only trials: 0
| Behavioral intervention and self-help trials: 0
Randomization
Protections against influence not in place | Medication-only trials: 0
| Behavioral intervention and self-help trials: 1^284^
Approach not described | Medication-only trials: 1^245^
| Behavioral intervention and self-help trials: 4^275,^,^279,^,^284,^,^294,298^
Whether randomization had a fatal flaw not known | Medication-only trials: 2^245,256^
| Behavioral intervention and self-help trials: 6^275,^,^279,^,^284,^,^286,^,^289,^,^294,298^
Comparison group(s) not similar at baseline | Medication-only trials: 2^245,256^
| Behavioral intervention and self-help trials: 1^289^
Blinding
Study subjects | Medication-only trials: 0
| Behavioral intervention and self-help trials: 1^289^
Investigators | Medication-only trials: 0
| Behavioral intervention and self-help trials: 1^289^
Outcomes assessors | Medication-only trials: 2^245,256^
| Behavioral intervention and self-help trials: 7^275,^,^279,284^–^286,^,^289,^,^294,298^
Interventions
Interventions not clearly described | Medication-only trials: 0
| Behavioral intervention and self-help trials: 0
No reliable measurement of patient compliance | Medication-only trials: 1^256^
| Behavioral intervention and self-help trials: 3^279,^,^285,289^
Outcomes
Results not clearly described | Medication-only trials: 0
| Behavioral intervention and self-help trials: 0
Adverse events not reported | Medication-only trials: 0
| Behavioral intervention and self-help trials: 6^275,^,^279,284^–^286,289^
Statistical Analysis
Statistics inappropriate | Medication-only trials: 0
| Behavioral intervention and self-help trials: 0
No controls for confounding (if needed) | Medication-only trials: 1^245^
| Behavioral intervention and self-help trials: 1^289^
Intention-to-treat analysis not used | Medication-only trials: 1^256^
| Behavioral intervention and self-help trials: 5^275,284^–^286,289^
Power analysis not done or not reported | Medication-only trials: 1^245^
| Behavioral intervention and self-help trials: 7^275,^,^279,284^–^286,^,^289,^,^294,298^
Results
Loss to followup 26% or higher or not reported | Medication-only trials: 0
| Behavioral intervention and self-help trials: 2^289,^,^294,298^
Differential loss to followup 15% or higher or not reported | Medication-only trials: 1^245^
| Behavioral intervention and self-help trials: 3^275,^,^286,289^
Outcome measures not standard, reliable, or valid in all groups | Medication-only trials: 0
| Behavioral intervention and self-help trials: 0
Discussion
Results do not support conclusions, taking possible biases and limitations into account | Medication-only trials: 0
| Behavioral intervention and self-help trials: 0
Results not discussed within context of prior research | Medication-only trials: 1^256^
| Behavioral intervention and self-help trials: 0
External validity: population not representative of US population relevant to these treatments | Medication-only trials: 1^256^
| Behavioral intervention and self-help trials: 6^279,284^–^286,^,^289,^,^294,298^
Funding/sponsorship not reported | Medication-only trials: 0
| Behavioral intervention and self-help trials: 4^279,^,^285,^,^286,289^

### Participants

Of the 38 studies rated fair or good, 19 were conducted in the United States, five in Canada, four in Germany, three in the United Kingdom, two in Australia, and one each in Austria, Finland, New Zealand, and Norway. In addition, one multinational trial had US and Canadian sites; another had German and Australian sites.

Of the fair and good studies, three failed to report the age of participants; of the remainder, the age range of participants was 16 to 61 years with the majority of participants being adults. A total of 3,403 individuals participated in fair or good clinical trials for BN. From those that reported sex, 2,985 women and 23 men participated.

Thirty-one studies failed to report the race or ethnicity of participants. Of those that did, 1,203 participants were identified as white, 79 as nonwhite, 27 as African American, 40 as Hispanic American, 30 as Asian or Pacific Islander, and one as Native American.

Similar to the AN studies, some BN trials also had high attrition. Table 13 documents the percentages of dropouts in total and in each arm of the study. Three studies had five study groups; those are combined with information relating to the fourth treatment group.

Table 13 Dropout rates for randomized controlled trials: bulimia nervosa

Author | Total Enrollment, N | Total Dropouts N (% dropout) | G1 Treatment (% Dropout) | G2 Treatment (% Dropout) | G3 Treatment (% Dropout) | G4 Treatment (% Dropout) G5 Treatment (% Dropout)
Medication Trial
Beumont et al., 1997^244^ | 67 | 27 (40%) | Fluoxetine (50%) | Placebo (30%)
Fichter et al., 1991^248^ | 39 | 0 (0%) | Fluoxetine (0%) | Placebo 0%
Fluoxetine BN Collaborative Study Group, 1992^249^ | 387 | 117 (30%) | Placebo (37%) | Fluoxetine, 20 mg (23%) | Fluoxetine, 60 mg (30%)
Goldstein et al.,1995^250^ | 398 | 173 (43%) | Fluoxetine (40%) | Placebo (52%)
Kanerva et al., 1995^252^ | 50 | 4 (8%) | Fluoxetine (8%) | Placebo (8%)
Romano et al., 2002^254^ | 150 | 131 (87%) | Fluoxetine (83%) | Placebo (92%)
Fichter et al., 1996^247^ and Fichter et al., 1997^299^ | 72 | 24 (33%) | Fluvoxamine (51%) | Placebo (14%)
Pope et al., 1989^255^ | 46 | 4 (9%) | Trazodone (13%) | Placebo (4%)
Hoopes et al., 2003^251^ and Hedges et al., 2003^259^ | 68 | 28 (41%) | Topiramate (34%) | Placebo (47%)
Kennedy et al., 1993^253^ | 36 | 8 (21%) | Brofaromine (21%) | Placebo (24%)
Faris et al., 2000^246^ | 26 | 1 (4%) | Ondansetron (7%) | Placebo 0%
Walsh et al., 1991^257^ | 78 | 15 (19%) | Placebo (16%) | Desipramine (23%)
Medication Plus Behavior Intervention Trials
Goldbloom et al.,1997^261^ | 76 | 33 (43%) | Fluoxetine (39%) | CBT (35%) | Fluoxetine + CBT (55%)
Mitchell et al., 2001^262^ | 91 | 2 (2%) | Placebo (5%) | Fluoxetine (0%) | Placebo + self-help manual (0%) | Fluoxetine + self-help manual (5%)
Walsh et al., 2004^265^ | 91 | 63 (69%) | Fluoxetine + guided self help (54%) | Placebo + guided self help (88%) | Fluoxetine (70%) | Placebo (64%)
Agras et al., 1992^260^ and Agras et al., 1994^300^ | 71 | 18 (25%) | Desipramine 16 weeks (NR) | Desipramine 24 weeks (NR) | Desipramine 16 weeks + CBT (NR) | Desipramine 24 weeks + CBT (NR)
| | | | | | CBT (NR)
Mitchell et al., 2002^263^ | 62 | 25 (40%) | IPT (32%) | Antidepressant medication (48%)
Walsh et al., 1997^264^ and Wilson et al., 1999^301^ | 120 | 41 (34%) | CBT + medication (NR) | CBT + Placebo (NR) | Supportive therapy + medication (NR) | Supportive therapy + placebo (NR)
| | | | | | Medication only (43%)
Behavioral Intervention Trials
Agras et al., 2000^269^ | 220 | 57 (26%) | CBT (28%) | IPT (24%)
Wolk and Devlin, 2001^268^ | 110 | 44 (40%) | CBT (NR) | IPT (NR)
Cooper and Steere, 1995^274^ | 31 | 4 (13%) | CBT (13%) | Behavioral therapy (13%)
Fairburn et al., 1991^276^ and Fairburn et al., 1993^267^ | 75 | 15 (20%) | CBT (16%) | Behavioral therapy (24%) | IPT (12%)
Wilfley et al., 1993^287^ | 56 | 8 (14%) | CBT (33%) | IPT (11%) | Waiting list (0%)
Wilson et al., 2002^288^ | 220 | Post treatment: 66 (30%), Follow up: 91 (41%) | CBT (NR) | IPT (NR)
Garner et al., 1993^278^ | 60 | 10 (17%) | CBT (17%) | Supportive expressive (17%)
Hsu et al., 2001^280^ | 100 | 27 (27%) | Nutritional therapy (39%) | Cognitive therapy (15%) | Cognitive and nutritional therapy (11%) | Sequential group (46%)
Sundgot-Borgen et al., 2002^283^ | 64 | 6 (9%) | Exercise (20%) | CBT (13%) | Nutrition (0%) | Waiting list (6%)
| | | | | | Healthy control (0%)
Chen et al., 2003^273^ | 60 | 16 (27%) | Individual CBT (27%) | Group CBT (27%)
Agras et al., 1989^266^ | 77 | 67 (13%) | Waiting list (5%) | Self monitoring (16%) | CBT (23%) | CBT + response prevention (6%)
Bulik et al., 1998^270^ and Bulik et al.,1998^271^ | 111 | 5 (5%) | Exposure to B-ERP (5%) | Exposure to P-ERP (6%) | Relaxation training (3%)
Laessle et al., 1991^281^ | 55 | 7 (13%) | Nutritional management (19%) | Stress management (7%)
Safer, Telch, and Agras, 2001^282^ | 31 | 2 (6%) | Dialectical behavior therapy (13%) | Waiting list (7%)
Self-help Trials
Bailer et al., 2004^290^ | 81 | 25 (31%) | Self help (25%) | CBT (37%)
Carter et al., 2003^291^ | 85 | 20 (24%) | CBT (18%) | Nonspecific (25%) | Waiting list (28%)
Durand and King, 2003^292^ | 68 | 14 (21%) | GP self-help (24%) | Specialist treatment (18%)
Thiels et al., 1998^293^ | 62 | 13 (21%) | CBT (13%) | Guided self change (29%)
Other Interventions
Braun et al., 1999^295^ | 34 | 10 (29%) | Active light (31%) | Dim light (28%)
Mitchell et al., 2004^297^ | 57 | 17 weeks: 9 (16%); | Crisis prevention 17 weeks: (10%), | Follow up 17 weeks: (22%),
| | 43 weeks: 16 (28%), | 43 weeks: (23%), | 43 weeks: (33%),
| | 70 weeks: 23 (40%) | 70 weeks: (37%) | 70 weeks: (44%)
Esplen et al., 1998^296^ | 58 | 8 (14%) | Guided imagery (14%) | Control (13%)

B-ERP, exposure therapy with response prevention for bingeing; CBT, cognitive behavioral therapy; GP, general practitioner; IPT, interpersonal psychotherapy; N, number; NR, not reported; P-ERP, exposure therapy with response prevention for purging.

## Key Question 1: Treatment Efficacy

### Medication-only Trials

We report on 12 randomized controlled double-blind medication-only trials (Table 14). The total number of individuals enrolled was 1,430. Based on studies that reported sex, 1,364 women and 21 men participated in medication-only trials. The number of participants ranged from 26 to 398. The age of participants ranged from 16 to 55. Two trials reported the race of participants; in these, 521 individuals were reported as white and 27 as nonwhite. Seven trials were conducted in the United States, two in Canada, and one each in Australia, Germany, and Finland.

Table 14 Results from medication trials: bulimia nervosa

Source, Treatment, Setting, and Quality Score | Major Outcome Measures | Significant Change Over Time Within Groups | Significant Differences Between Groups at Endpoint | Significant Differences Between Groups in Change Over Time
Beumont, Russell et al., 1997^244^ | Eating:; - BSQ; - Bulimic episodes; - EAT; - EDE; - Vomiting | Both groups decreased bulimic and vomiting episodes, ED concerns and symptoms; and worries about body shape at week 4. | Fluoxetine associated with lower restraint, weight concern, and shape concern at week 8 | Significant difference on weight at 8 weeks with weight decreasing in fluoxetine group and increasing in placebo group.
Fluoxetine vs. placebo | Biomarker:; - Weight | Both groups decreased bulimic and vomiting episodes; ED concerns and symptoms; worries about body shape; restraint, overeating, and concerns about eating, shape, and weight at week 8. | | Fluoxetine group regained weight above baseline at FU while placebo group did not.
Outpatient | Psych:; - HDRS | Both groups decreased bulimic and vomiting episodes, restraint, overeating, and concerns about eating and shape at 3-month FU. Fluoxetine group increased weight at 3 month FU.
Fair
Fichter et al., 1991^248^ | Eating:; - Binge attacks; - Binge urge; - EDI; - SIAB | No statistics reported. | No differences on any measures. | No differences on any measures.
Fluoxetine vs. placebo | Biomarker:; - Weight
Inpatient | Psych:; - CGI; - HAM-D; - SCL-90
Good
Fluoxetine BN Collaborative Study Group, 1992^249^ | Eating:; - Bingeing; - Vomiting; - EAT; - EDI; - Carbohydrate craving | No statistics reported. | Fluoxetine (60 mg) associated with greater reductions in binge eating and vomiting than fluoxetine (20 mg) or placebo. Fluoxetine (60 mg and 20 mg) associated with greater reductions in vomiting, weight, drive for thinness, bulimic intensity, carbohydrate craving, body dissatisfaction, and food and diet preoccupation than placebo. | No statistics reported.
Fluoxetine (20 mg) vs. fluoxetine (60 mg) vs. placebo | Biomarker:; - Weight | | Fluoxetine (60 mg) associated with greater reductions in depressed mood, drive for thinness, oral control, and bulimia scores than placebo.
Outpatient | Psych:; - HDRS
Fair
Goldstein, Wilson, Thompson et al., 1995^250^ | Eating:; - Binge eating; - Vomiting; - EDI | No statistics reported. | Fluoxetine associated with greater median percentage reduction in vomiting (at weeks 1–10, 13, 16, and endpoint) and binge eating (at weeks 1–9, 13, 16, and endpoint); greater reduction in total bulimia symptoms, drive for thinness, global symptoms scores, and weight; greater tx response (≥ 50% improvement in bulimic episodes) | No statistics reported.
Fluoxetine vs. placebo | Biomarker:; - Weight
Outpatient | Psych:; - CGI; - HRSD; - PGI
Fair
Kanerva, Rissanen, and Sarna, 1994^252^ | Eating:; - Bingeing; - BITE; - EAT; - EDI | At 4 weeks, fluoxetine group decreased anxious mood and state anxiety. | No statistics reported | Fluoxetine associated with greater reduction in depressed and anxious mood, bulimia and food preoccupation over 8 weeks. Difference in weight with decrease in fluoxetine group and increase in placebo group.
Fluoxetine vs. placebo | Biomarker:; - Weight
Outpatient | Psych:; - HDRS-17; - HDRS-21; - STAI
Fair
Romano et al., 2002^254^ | Eating:; - Bingeing; - EDI; - Relapse; - Vomiting; - YBC-EDS | Both groups worsened over the 52-week extended tx period. | No statistics reported. | Fluoxetine group had smaller mean increases in vomiting, binge eating, total ED behavior, ritual, preoccupation and symptom severity. Relapse occurred less frequently in the first 3 months of 52-week extended tx period.
Fluoxetine vs. placebo | Biomarker:; - BMI
Outpatient | Psych:; - CGI; - HDRS
Fair
Fichter et al., 1996^247^ | Eating:; - Abstinence; - Bingeing; - EDI; - Relapse; - SIAB; - Urge to binge | No statistics reported. | Fluvoxamine associated with higher binge abstinence rate, reduced clinical severity, and lower relapse rate. | Fluvoxamine superior in limiting increases in bulimic behavior (urge to binge, vomiting), global ED symptoms (SIAB total), EDI bulimia scores, fear of losing control, obsessive-compulsive symptoms, and, global severity during 12 week post-discharge relapse prevention phase.
Fichter et al., 1997^299^ | Biomarker:; - BMI
Fluvoxamine vs. placebo | Psych:; - CGI; - HDRS; - HSCL
Inpatient and outpatient
Fair
Pope et al., 1989^255^ | Eating:; - Binge frequency; - EDI; - Vomit frequency; - Fear of eating | Trazadone group decreased binge and purge frequencies and fear of eating at 6 wks. | Trazadone associated greater percent decrease in binge and vomit frequencies and decrease in fear of eating and increase in self-esteem | No statistics reported.
Trazadone vs. placebo | Psych:; - Self-control; - Self-esteem; - HAM-A; - HAM-D
Outpatient
Fair
Hoopes et al., 2003;^251^ | Eating:; - Binge days; - Bulimic intensity scale; - Carbohydrate craving; - EAT; - EDI; - Purge days; - Remission | No statistics reported. | Topiramate associated with greater percentage reduction in weekly number of binge and purge days, carbohydrate craving score, bulimic intensity, lower mean global symptoms and symptom intensity; and greater mean weight reduction. | Topiramate superior to placebo in reducing uncontrolled eating, body dissatisfaction, dieting, food preoccupation,and anxious mood, and in increasing patient-rated percent improved.
Hedges et al., 2003^259^ | Biomarker:; - Weight | | Larger percentage of topiramate group achieved moderate (> 50% reduction) or marked (> 75% reduction) improvement in weekly binge/purge days.
Topiramate vs. placebo | Psych:; - CGI; - HAM-A; - HAM-D; - PGI
Outpatient
Fair
Kennedy et al., 1993^253^ | Eating:; - Binge episodes; - EAT-26; - EDI; - Non-binge meals; - Vomiting episodes | No statistics reported. | Brofaromine associated with greater reduction in vomiting episodes. | No statistics reported
Brofaromine vs. placebo | Biomarker:; - BMI; - Weight | | A greater percentage of brofaromine group lost > 1 kg of weight. A greater percentage of placebo group gained > 1 kg of weight.
Outpatient | Psych:; - HAM-A; - HAM-D
Fair
Faris et al., 2000^246^ | Eating:; - Binge-purge episodes; - Normal meals; - Time spent in BN behaviors | Ondansetron group increased average number of normal meals, and decreased time spent engaging in BN behaviors at week 4. | Ondansetron associated with lower binge/purge frequency at week 4. | Ondansetron superior in reducing binge/vomit frequency and time spent engaging in BN behaviors and in increasing normal meals over 4 weeks.
Ondansetron vs. placebo | Biomarker:; - Weight
Inpatient and outpatient
Good
Walsh et al., 1991^257^ | Eating:; - Binge episodes; - BSQ; - EAT; - Remission; - Vomiting episodes | No statistics reported. | Desipramine associated with fewer binge and vomiting episodes/week, fewer ED symptoms and body shape concerns, lower BMI, fewer symptoms of depression, global symptoms, and obsessive/compulsiveness, less hostility and trait anxiety. | No statistics reported.
Desipramine vs. placebo | Biomarker:; - BMI
Outpatient | Psych:; - BDI; - HAM-D; - SCL-90; - Social adjustment scale; - STAI
Fair

BDI, Beck Depression Inventory; BITE, Bulimic Investigation Test Edinburgh; BMI, Body mass index; BSQ, Body Shape Questionnaire; CGI, Clinical Global Impression Scale; EAT, Eating Attitudes Test [EAT-26 items]; ED, Eating disorder; EDE, Eating Disorder Examination; EDI, Eating Disorders Inventory; FU, followup; HAM-A, Hamilton Anxiety Index; HAM-D (or HDRS), Hamilton Depression Rating Scale [HDRS-17 items, HDRS-21 items]; HRSD, Hamilton Rating Depression Scale; HSCL, Hopkins Symptom Check List (see SCL-90); kg, kilogram; PGI, Patient Global Impression; Psych, psychiatric and psychological; SCL, (Hopkins) Symptom Check List (SCL-90 items); SIAB, Structured Interview for Anorexia and Bulimia nervosa; STAI, Spielberger State-Trait Anxiety Inventory; tx, treatment; YBC-EDS, Yale-Brown-Cornell Eating Disorder Scale.

The medication-only trials used the following two designs: medication versus placebo (10) and medication (dose a) versus medication (dose b) versus placebo (1). The results of these studies are presented below by drug class.

Second-generation antidepressants. Fluoxetine. Six trials compared fluoxetine to placebo in outpatient and inpatient settings. The mean age of participants was mid-twenties; no studies of fluoxetine focused exclusively on adolescents.

Overall, fluoxetine (60 mg/day) administered for between 8 weeks and 16 weeks led to significant reductions in binge eating in most^244,^ ^249,^ ^250,^ ^254^ but not all studies.^248,^ ^252^ Fluoxetine (60 mg/day) also performed significantly better than fluoxetine (20 mg/day) in decreasing binge eating.^249^ No effect of fluoxetine (60 mg/day) compared with placebo was observed in the one study in which patients were already receiving intensive inpatient psychotherapy.^248^

Fluoxetine (60 mg/day) was superior to placebo in decreasing purging behavior,^244,^ ^249,^ ^250,^ ^254^ although not in the inpatient setting.^248^

All six fluoxetine trials either failed to report abstinence rates (absence of binge eating and purging behaviors) or did not report whether abstinence rates differed significantly between drug and placebo groups.

With reference to eating-related attitudes, fluoxetine (60 mg/day) was associated with significant improvements in measures of restraint, weight concern, and food preoccupation and with Eating Disorders Inventory (EDI) subscale scores of bulimia, drive for thinness, and body dissatisfaction.^244,^ ^249,^ ^250,^ ^254^ Again, the exception was the inpatient study.^248^

Fluoxetine had mixed results on depression and anxiety scores. Some studies showed greater efficacy than placebo in decreasing depression scores,^249,^ ^252^ but others showed no advantage of fluoxetine.^244,^ ^248,^ ^250,^ ^254^

One study explored the efficacy of fluoxetine (60 mg/day) versus placebo in preventing relapse of BN over 52 weeks.^254^ Relapse rates were significantly lower for those receiving fluoxetine (33 percent) than for those receiving placebo (51 percent). However, dropout was substantial during the observation period (83 percent in the fluoxetine group and 92 percent in the placebo group).

Drop-out rates in fluoxetine arms of these trials ranged from zero (in an inpatient study) to 50 percent (three studies had greater than 40 percent dropout). In one study, dropout was greater in the fluoxetine than in the placebo group,^244^ in three studies placebo had greater attrition,^249,^ ^250,^ ^254^ and one inpatient study reported no dropout in either group.^248^

Fluvoxamine. To compare maintenance of therapeutic gains and prevention of relapse of BN after inpatient treatment, Fichter et al. compared fluvoxamine (average dose 182 mg/day) with placebo for 19 weeks.^247^ Patients treated with fluvoxamine reported fewer urges to binge, lower frequency of vomiting, and lower depression scores than those receiving placebo. Both groups gained weight, with no differences between groups. Fluovoxamine was associated with a lower relapse rate. However, attrition was high (51 percent for those on fluovoxamine and 14 percent for those on placebo).

Trazodone. In a 6-week trial of trazodone (400 mg) versus placebo, trazodone led to significantly greater decreases in the frequency of binge eating and vomiting and decreased fear of eating.^255^ No differences in depression or anxiety were observed, although baseline levels were not indicative of severe depression.

Tricyclic antidepressants. One 6-week trial of desipramine (200–300 mg/day) versus placebo found the active drug to be significantly more effective than placebo in decreasing binge eating, vomiting, and scores on the Eating Attitudes Test (EAT) and Body Shape Questionnaire (BSQ).^257^ Abstinence rates from binge eating and purging did not differ between active drug and placebo. Both self-reported depression and anxiety were significantly decreased in the desipramine group compared with the placebo group; clinician-rated depression did not differ significantly. Patients in the desipramine group lost significantly more weight than those in the placebo group, who tended to gain weight. Dropout was 23 percent in the desipramine group and 16 percent in the placebo group.

Anticonvulsants. The single 10-week trial of the anticonvulsant topiramate (mean dose 100 mg/day) led to significantly greater reductions than placebo in the number of binge/purge days reported and in body dissatisfaction, drive for thinness, and EAT scores.^251,^ ^259^ Abstinence rates from binge eating and purging were 22.6 percent for topiramate and 6 percent for placebo (not significantly different). Topiramate was associated with significant reductions in anxiety but not depression, and the topiramate group lost significantly more weight than the placebo group, who tended to gain weight. Dropout from topiramate treatment was 34 percent and 47 percent for placebo.

MAOI. One 8-week trial of brofaromine (mean dose 175 mg/day) revealed no differences between the active drug and placebo on binge eating or psychological features of the eating disorder.^253^ Brofaromine did lead to significant reductions in vomiting. Abstinence from binge eating and from vomiting were measured independently and did not differ between groups; no differences were observed on depression or anxiety scores, weight change, or drop-out rates (21 percent brofaromine and 24 percent placebo).

5HT3 antagonist. In a small 4-week trial of ondansetron versus placebo—self-administered when patients had an urge to binge or vomit—the active drug led to significantly greater decreases than placebo in binge and vomit frequencies and time spent in bulimic behavior, and to significant increases in normal meals.^246^ The investigators did not measure depression or anxiety, and they found no differences in weight change. One patient dropped out from ondansetron, none from placebo.

Summary of medication-only trials. Fluoxetine (60 mg/day) administered for 6 to 18 weeks has been shown in several fair- to good-rated trials to reduce the core bulimia symptoms of binge eating and purging and associated psychological features of the eating disorder in the short term. The 60 mg dose performs better than the 20 mg dose;^249^ it was also associated with prevention of relapse at 1 year in a study with considerable dropout.^254^ Considerable evidence exists for the use of 60 mg/day of fluoxetine to treat BN in the short term. Evidence for the long-term effectiveness of relatively brief medication treatment does not exist. The optimal duration of treatment and the optimal strategy for maintenance of treatment gains are unknown.

Single studies provide preliminary evidence of the efficacy of two other second-generation antidepressants, namely trazodone^255^ and fluvoxamine.^247^ Likewise, evidence from single studies provides preliminary evidence of the efficacy of desipramine^257^ and topiramate.^251^ One preliminary trial of ondansetron, a 5HT3 antagonist and antiemetic, led to an intriguing decrease in binge eating and vomiting when patients could self-administer when they had urges to binge or purge.^246^ This innovative study requires replication. One trial of brofaromine, an MAOI, showed a significantly greater effect on reducing vomiting than placebo.^253^

When reported, abstinence rates in medication-only trials suggest that medication treatment leads to abstinence in a minority of individuals. This finding indicates that although bulimia symptoms improved, they nonetheless persisted.

Drop-out rates in medication trials ranged from zero to 51 percent. No drug showed substantially greater attrition than others.

## Medication Plus Behavioral Intervention Trials

We present the six trials of medications plus behavioral interventions in Table 15. These trials used a variety of designs to determine the extent to which a combination intervention is superior to either medication or behavioral intervention alone.

Table 15 Results from medication plus behavioral intervention trials: bulimia nervosa

Source, Treatment, Setting, and Quality Score | Major Outcome Measures | Significant Change Over Time Within Groups | Significant Differences Between Groups at Endpoint | Significant Differences Between Groups in Change Over Time
Goldbloom et al., 1997^261^ | Eating:; - Binge episodes; - EDE; - EDI; - Vomiting episodes | Decreased shape and weight concerns in the fluoxetine and the fluoxetine + CBT groups. | At tx completion, CBT alone and fluoxetine + CBT associated with greater percent reduction in vomiting frequency, compared to fluoxetine alone. | No statistics reported.
Fluoxetine vs. CBT vs. fluoxetine + CBT | Biomarker:; - Weight | | At 4 weeks post-tx, fluoxetine + CBT associated with fewer objective binge and vomit weekly episodes compared to fluoxetine alone.
Outpatient | Psych:; - BDI; - RSE | | CBT associated with fewer subjective binge episodes compared to fluoxetine alone.
Fair | | | Note: no sig diff in ITT analyses.
Mitchell et al., 2001^262^ | Eating:; - Abstinence; - Binge eating; - EDI; - SIAB; - Fasting days; - Vomiting | No statistics reported. | Fluoxetine, alone and with self-help, associated with greater percentage reduction in vomiting and greater clinician-rated and patient-rated clinical improvement, compared to self help plus placebo or placebo alone, at endpoint (16 week tx period). | No statistics reported.
Fluoxetine vs. placebo vs. self-help + placebo vs. fluoxetine + self-help | Psych:; - CGI; - HAM-D; - PGI | | Self-help manual plus placebo or fluoxetine associated with greater percentage reduction in vomiting compared to placebo or fluoxetine with no self-help manual, at 4-week time point (after 2 weeks active tx).
Outpatient
Fair
Walsh et al., 2004^265^ | Eating:; - EDE (episodes of bulimia, laxative use, vomiting); - Restraint | No statistics reported. | Fluoxetine associated with fewer objective bulimic and vomiting episodes and fewer vomiting days per month, less restraint, less depressed mood, and a lower general symptom index compared to placebo. Fluoxetine only and placebo groups greater decrease in bulimic episodes than self-help groups. | No statistics reported
Fluoxetine vs. placebo vs. guided self-help vs. fluoxetine + guided self-help | Biomarker:; - BMI
Outpatient | Psych:; - BDI; - SCL-53
Good
Agras et al., 1992;^260^ and Agras et al., 1994^300^ | Eating:; - Abstinence; - Bingeing; - Dietary preoccupation; - Disinhibition; - EDE; - Hunger; - Purging; - Recovery | No statistics reported. | No statistics reported. | Desipramine + CBT superior to medication alone in reducing binge and purge frequency at 16 and 32 weeks, and in reducing diet preoccupation over 16 weeks.
Desipramine (16 weeks) vs. desipramine (24 weeks) vs. desipramine + CBT (16 weeks) vs. desipramine + CBT (24 weeks) vs. CBT alone (24 weeks) | Biomarker:; - Weight | | | Desipramine + CBT superior to CBT alone in reducing hunger disinhibition over 24 weeks, and superior to medication alone in reducing diet preoccupation at 16 weeks.
Outpatient | Psych:; - BDI; - RSE | | | CBT alone superior to desipramine alone for 16 or 24 wks in reducing binge and purge frequency at 16 wks. CBT alone or in combination with desipramine for 24 weeks, superior to desipramine for 16 weeks in reducing binge frequency at 1 year FU.
Fair | | | | Desipramine + CBT for 24 weeks superior to desipramine for 16 weeks in reducing binge frequency, hunger, disinhibition, and diet preoccupation at 1 year FU.
Mitchell et al., 2002^263^ | Eating:; - Abstinence; - BSE; - BAQ; - EDE; - Objective binges; - Relapse; - TFEQ | No statistics reported. | No differences on any measures. | No statistics reported.
IPT vs. fluoxetine (16 weeks) or vs. fluoxetine (8 weeks) followed by desipramine (8 weeks) | Psych:; - BDI
Outpatient
Fair
Walsh et al., 1997^264^ and Wilson et al., 1999^301^ | Eating:; - Bingeing; - BSQ; - EAT; - EDE; - Remittance; - Vomiting | All groups exhibited decreases in weekly bingeing and vomiting, EAT and BSQ scores, concerns about eating and eating restraint, global ED symptoms, and depressed mood. | No statistics reported. | CBT groups combined superior to supportive therapy groups combined in reducing binge and vomit episode frequencies. Behavioral interventions plus medication superior to behavioral interventions alone in reducing binge frequency, EAT scores, depressed mood, weight, and in increasing remission rate. CBT plus medication superior to medication alone in reducing binge and vomit frequencies, EAT scores, body image, and increasing remission rate by self-report. Medication alone superior to CBT alone in reducing BMI and weight. Medication alone superior to supportive therapy plus medication in reducing binge and vomit frequency.
CBT + placebo vs. CBT + medication (desipramine only or desipramine followed by fluoxetine) vs. Supportive therapy + placebo vs. Supportive therapy + medication vs. Medication alone | Biomarker:; - BMI; - Weight | Weight and BMI decreased in 3 groups (CBT+ placebo, medication alone, and supportive therapy + medication). Anxiety decreased in each of the 3 groups receiving medication.
Outpatient | Psych:; - BDI; - SCL-90 | Importance of shape and weight concerns decreased in two groups (CBT plus placebo and supportive therapy plus medication).
Fair

BDI, Beck Depression Inventory; BES, Binge Eating Scale; BMI, body mass index; BSQ, Body Shape Questionnaire; CBT, cognitive behavior therapy; CGI, clinical global impression; EAT, Eating Attitudes Test; ED, eating disorders; EDE, eating disorders examination; EDI, eating disorder inventory; FU, followup; HAM-D, Hamilton Rating Score for Depression; ITT, intention-to-treat; IPT, interpersonal psychotherapy; PGI, patient global impression; Psych, psychiatric and psychological; RSE, Rosenberg Self-Esteem Questionnaire; SCL, (Hopkins) Symptom Checklist (SCL-53 items, SCL-90 items); TFEQ, Three Factor Eating Questionnaire; tx, treatment; vs., versus; YBC-ED, Yale-Brown-Cornell Eating Disorder Scale.

The total number of individuals enrolled in these combination trials was 1,895. The number of participants in the medication plus psychotherapy trials ranged from 71 to 120. No men participated in these trials. Participant ages ranged from 18 to 46. Three trials reported race or ethnicity of participants: 272 individuals were reported to be white, seven nonwhite, two Hispanic American, eight African American, and seven Asian. Five of these trials were conducted in the United States and one in Canada.

Second-generation antidepressants and CBT. Three trials used fluoxetine as the drug intervention. Comparing fluoxetine (60 mg/day) to CBT only to fluoxetine (60 mg/day) plus CBT in a 12-week trial, Goldbloom et al. used intention-to-treat analyses but found no difference across groups on eating related-measures.^261^ In completers, all three interventions led to significant improvement in core bulimic symptoms; however, both combined treatment and CBT alone led to greater decreases than fluoxetine alone in objective and subjective binges and vomiting episodes. Abstinence rates, depression scores, and weight did not differ across groups. Dropout was highest in combined treatment (55 percent) compared to the fluoxetine (39 percent) and CBT only groups (35 percent). The investigators did not provide long-term followup data.

Walsh et al. compared fluoxetine (60 mg/day) with placebo, each with or without self-help in the form of a cognitive-behavioral self-help book^302^ with instructions for use.^265^ Physicians and nurses in primary care provided the treatments. Fluoxetine (either alone or with self-help) was associated with significantly decreased objective binge episodes, vomiting, restrained eating, and depression. The self-help book had no independent effect. No differences emerged on weight change. Dropout was high: 54 percent in fluoxetine plus guided self-help to 88 percent in placebo plus guided self-help.

Using the same design but a different self-help manual, also based on principles of CBT, and administering treatment from a specialized eating disorders program, Mitchell et al. found fluoxetine to be associated with a significantly greater decrease than placebo in vomiting episodes but not binge eating episodes.^262^ No significant differences emerged in abstinence rates or depression. At the end of treatment, the investigators reported no independent effect of self-help. Dropout was low: none in fluoxetine only and fluoxetine plus self-help, 5 percent in placebo only and placebo plus self-help.

Tricyclic antidepressants and CBT. One complex trial compared desipramine treatment of different durations with or without CBT (16 versus 24 weeks) with CBT only.^260^ The 16-week combined treatment was better than drug only for decreasing binge eating and purging. Longer combined treatment was significantly better than drug only on binge eating, vomiting, dieting preoccupation, and hunger. Abstinence rates did not differ across groups. The authors did not report results concerning depression. Weight change did not differ significantly across groups. At 1-year followup, the combined 24-week intervention and CBT alone were both better than the 16-week drug only treatment in decreasing binge eating and vomiting. The 24-week combined treatment was also superior to 16-week drug only in decreasing binge frequency, dietary preoccupation, disinhibition, and hunger.^300^ In all but the medication-only group, between 78 percent and 100 percent of individuals who were abstinent at the end of treatment remained abstinent at followup. The overall drop-out rate was 25 percent.

Multiple drugs and CBT. Walsh et al. examined supportive psychotherapy, CBT, both with or without placebo and with or without medication, and medication alone in a five-group 16-week comparison.^264,^ ^301^ They started patients on desipramine (mean dose 188 mg/day) and switched nonresponders to fluoxetine (60 mg/day) after 8 weeks. Analyses combining all arms of the study that included CBT versus all arms of the study that included supportive therapy indicated that CBT was superior to supportive therapy in reducing binge and vomit episode frequencies. Behavioral interventions plus medication were superior to behavioral interventions alone in reducing binge frequency, EAT scores, depressed mood, weight, and in increasing remission rate.

CBT plus medication was superior to medication alone in reducing binge and vomit frequencies, EAT scores, body image, and increasing remission rate by self-report. Medication alone was superior to CBT alone in reducing BMI and weight. Medication alone was superior to supportive therapy plus medication in reducing binge and vomit frequency. Medication led to significantly greater decreases in depression scores. CBT was associated with greater likelihood of remission. The overall drop-out rate was 34 percent.

Mitchell et al. randomized patients who did not respond to CBT to either interpersonal psychotherapy or fluoxetine (60 mg/day), which could be switched to desipramine in those who did not achieve abstinence.^263^ No difference in abstinence was observed between the two groups. Overall, the sequential second-level treatment was associated with high dropout.

Summary of medication plus psychotherapy trials. The combined medication plus behavioral intervention studies provide only preliminary evidence regarding the optimal combination of medication and psychotherapy or self-help. Given the variety of designs used and lack of replication, evidence remains weak. Combined CBT and fluoxetine and CBT alone led to greater decreases in binge eating and purging than fluoxetine alone in individuals who complete therapy.^261^ When delivered in the context of a specialist eating disorders program, both self-help and fluoxetine were associated with decreased vomiting; however, the addition of self-help to fluoxetine was not associated with increased efficacy.^262^ When these therapies were administered in a primary care setting, drop-out rates from fluoxetine (70 percent) and fluoxetine plus self-help (54 percent) were unacceptably high.^265^

The only study that looked at sequential treatment for individuals who did not respond to CBT revealed that the addition of interpersonal psychotherapy to fluoxetine (allowing the transition to desipramine) led to substantial attrition and minimal effects on subsequent abstinence rates. How best to treat individuals who do not respond to CBT or fluoxetine remains a major shortcoming of the literature.

### Behavioral Intervention Trials

We report 13 psychotherapy-only trials, four self-help trials, one trial of light therapy, one of guided imagery, and one of crisis prevention. Summary outcomes data for the psychotherapy trials appear in Table 16. The total number of individuals enrolled in psychotherapy, self-help, and other trials was 1,462. From the studies that reported sex of participants, 1,064 women and two men participated. Across these 20 trials, participants ranged in age from 17 to 64 years. Six trials reported race and ethnicity of participants: in all, 410 patients were white; 22 nonwhite; 28 Hispanic American; 26 Asian, Maori, or Pacific Islander; 10 African American; and 1 Native American. In no instance were results analyzed specifically by race or ethnicity group. Of the 20 trials, seven were conducted in the United States, three each in Canada and the United Kingdom, one each in Australia, Austria, Germany, New Zealand, and Norway, and one two-site study in Germany and Australia, and one did not report location.

Table 16 Results from behavioral intervention trials: bulimia nervosa

Source, Treatment, Setting, and Quality Score | Major Outcome Measures | Significant Change Over Time Within Groups | Significant Differences Between Groups at Endpoint | Significant Differences Between Groups in Change Over Time
Agras et al., 2000^269^ and Wolk and Devlin, 2001^268^ | Eating:; - Bingeing; - EDE; - Purging; - Remittance; - Recovery | No statistics reported. | CBT associated with higher percent remitted and percent recovered at end of tx (ITT analysis). | No statistics reported.
CBT vs. IPT | Biomarker:; - BMI | | In completers-only analysis, CBT associated with fewer objective binges and purges; less eating restraint; and less weight, shape, and eating concerns at the end of tx. Stage of change predicted improvement in IPT but not CBT.
Outpatient | Psych:; - SCL-90R; - Stage of change
Good
Cooper and Steere, 1995^274^ | Eating:; - Abstinence; - Bulimic episodes; - BSQ; - EAT; - EDE; - Dietary restraint; - Relapse; - Vomiting episodes | No statistics reported. | Relapse rate lower in cognitive therapy group among those who were abstinent from binge-eating at end of tx and at 12 month FU. | Cognitive therapy superior to exposure therapy in reducing vomiting and depression between baseline and 12 month FU.
Cognitive therapy vs. exposure plus binge and purge response prevention | Biomarker:; - Weight
Outpatient | Psych:; - BDI; - PSE; - MADRS; - STAI
Fair
Fairburn et al., 1991;^276^ Fairburn, Jones et al., 1993^267^ and Fairburn, Peveler et al., 1993^277^ | Eating:; - EAT; - EDE; - Laxative misuse; - Objective bulimic episodes; - Vomiting | No statistics reported. | No statistics reported. | Over 18 week tx period, CBT superior to BT and IPT in reducing eating restraint, weight concerns, and overall ED psychopathology; CBT superior to IPT in reducing vomiting; and CBT superior to BT in reducing shape concerns.
CBT vs. BT vs. IPT | Biomarker:; - BMI | | | Over 12-month FU, CBT superior to BT in improving abstinence.
Outpatient | Psych:; - BDI; - SCL-90; - RSE
Fair
Wilfley et al., 1993^287^ | Eating:; - Binge frequency; - EDE; - TFEQ | CBT and IPT decreased binge frequency at 1 year FU. | No statistics reported. | Group CBT and group IPT superior to waiting-list in reducing binge frequency, and disinhibition over 16 weeks.
Group CBT vs. group IPT vs. waiting-list control | Psych:; - BDI; - IIP; - RSE | | | Group IPT superior to waiting-list in reducing restraint over 16 weeks.
Outpatient
Fair
Wilson et al., 2002^288^ | Eating:; - Binge eating; - EDE; - Recovery; - Vomiting | Both groups decreased shape and weight concerns at post-tx. | CBT showed greater mean reduction in eating restraint by tx week 6, greater improvements in self-efficacy by tx week 10, and a higher percentage reduction in binge eating at post-tx. | CBT superior in early (by week 6) improvement (reduction in frequency of vomit episodes)
CBT vs. IPT | Psych:; - IIP; - RSE; - Self-efficacy
Outpatient
Fair
Garner et al., 1993^278^ | Eating:; - Binge episodes; - EAT; - EDE; - EDI; - Vomiting | No statistics reported. | No statistics reported. | Over 18 week tx period, CBT superior in reducing dieting, food preoccupation, eating concerns, restraint, attitudes toward shape, bulimia behaviors, depressed mood, global symptoms, and symptoms of borderline personality disorder and dysthymia; and in improving self-esteem.
CBT vs. supportive-expressive therapy | Biomarker:; - Weight
Outpatient | Psych:; - BDI; - Millon Inventory; - RSE; - SCL-90-R
Fair
Hsu et al., 2001^280^ | Eating:; - Bingeing; - EDI; - Meals/week; - Purging | No statistics reported. | No statistics reported. | CNT superior to NT alone and to group support in binge/purge abstinence and in reducing drive for thinness and BN symptoms.
CT vs. NT vs. CT+NT (CNT) vs. group support (control) | Psych:; - HDRS | | | CT superior to NT in reducing BN symptoms and CT superior to group support in reducing drive for thinness.
Outpatient
Fair
Sundgot-Borgen et al., 2002^283^ | Eating:; - Binge frequency; - EDI; - Vomit frequency; - Laxative abuse | Exercise group decreased percent body fat at post-tx and fat mass at 18-month FU. | Body dissatisfaction lower in CBT compared to nutritional counseling group at post tx. | No statistics reported.
Exercise vs. CBT vs. nutrition counseling vs. waiting-list vs. healthy controls | Biomarker:; - Percent body fat | | Laxative use lower in exercise than CBT group at post tx.
Outpatient | | | Vomit frequency, bulimia symptoms, and body dissatisfaction lower in CBT than nutritional counseling group at 6 month FU. Drive for thinness and laxative abuse lower in exercise than CBT group, at 6 month FU.
Fair | | | Binge episodes lower in exercise than in CBT at 18 month FU.
Chen et al., 2003^273^ | Eating:; - Abstinence; - Binge episodes; - EDE-12; - Laxative use; - Over-exercising; - Purge episodes | No statistics reported. | Higher rate of abstinence in individual CBT than group CBT at end of tx. | Group CBT superior to individual CBT in reducing state anxiety.
Individual CBT vs. group CBT | Biomarker:; - BMI
Outpatient | Psych:; - BDI; - SCL-90; - STAI
Fair
Agras et al., 1989^266^ | Eating:; - Abstinence; - Dieting urge; - Food preoccupation; - Purge/week | Decreased purges/week in self-monitoring, CBT, and CBT+ response groups at end of 4-month tx. | CBT associated with higher abstinence rate compared to waiting-list at end of tx, and compared to self-monitoring and response prevention at 6 month FU. | CBT alone superior to waiting-list in reducing purging frequency, increasing purging abstinence and decreasing depressed mood, by end of treatment.
Waiting-list vs. Self-monitoring vs. CBT vs. CBT+ response prevention | Biomarker:; - Weight | | | CBT alone and CBT+ response prevention superior to waiting-list in reducing depressed mood by end of treatment.
Outpatient | Psych:; - BDI
Fair
Bulik et al., 1998;^270^Bulik et al., 1998;^271^ Carter, McIntosh et al., 2003^272^ | Eating:; - Abstinence; - Bingeing; - Clinician ratings (food restriction, body dissatisfaction; - EDI; - Laxative use; - Purging; - Vomiting | P-ERP and relaxation groups improved body dissatisfaction at 3 yr FU | B-ERP associated with less drive for thinness, lower clinician-rated food restriction, body dissatisfaction, and depressed mood, lower subjective distress than relaxation training at 3 year FU. | Relaxation superior to B-ERP in reducing depressed mood and clinician-rated body dissatisfaction from post-tx to 2 year FU.
8 weeks CBT followed by B-ERP tx vs. P-ERP tx vs. relaxation training | Psych:; - HDRS; - GAFS; - SUDS | | P-ERP associated with fewer ED psychological and behavioral measures.than relaxation training at 3 year FU. | Relaxation superior to P-ERP in reducing ED psych and behavioral traits and depressed mood from post-tx to 3 year FU.
Outpatient | | | B-ERP associated with less food restriction, higher GAFS score than relax training at 12 month FU.
Good
Laessle et al., 1991^281^ | Eating:; - Binge frequency; - Calories/day; - EAT; - EDI; - Vomit frequency | No statistics reported. | No difference on any measures. | Nutritional management superior to stress management in increasing calorie consumption and decreasing binge frequency over first 3 weeks of tx, and in increasing binge abstinence rate through 6 and 12 months.
Nutritional management vs. stress management | Psych:; - BDI; - STAI | | | Stress management superior to nutrition management in reducing trait anxiety over 3 months of tx.
Outpatient
Fair
Safer et al., 2001^282^ | Eating: | No statistics reported. | DBT superior in post-tx abstinence rate | DBT superior in reducing the number of binge and purge episodes measured in last 4 of 20 weeks of tx.
DBT vs. waiting-list | Binge episodes
Outpatient | EDE
Good | Emotional eating scale
| Purge episodes
| Psych:
| BDI
| Positive and Negative Affect Schedule

B-ERP, exposure with response prevention to pre-binge cues; BDI, Beck Depression Inventory; BMI, Body mass index; BN, bulimia nervosa; BSQ, Body Shape Questionnaire; BT, Behavioral Therapy; CBT, Cognitive Behavioral Therapy; CNT, Cognitive nutritional therapy; CT, Cognitive Therapy; DBT, dialectical behavior therapy; EAT, Eating Attitudes Test; ED, Eating disorder; EDE, Eating Disorder Examination (EDE-12 items); EDI, Eating Disorders Inventory; FU, follow-up; GAFS, Global Assessment of Functioning Symptoms; HDRS, Hamilton Depression Rating Scale; IIP, Inventory of Interpersonal Problems; IPT, interpersonal psychotherapy; ITT, intention-to-treat; MADRS, Montgomery and Asberg Depression Rating Scale; NT, nutritional therapy; P-ERP, exposure with response prevention to pre-purge cues; PSE, Present State Examination; Psych, psychiatric and psychological; RSE, Rosenberg Self-Esteem Scale; SCL-90, (Hopkins) symptom checklist (SCL-90 items, SFL-90-R [SCL-90-revised]); STAI, Speilberger State-Trait Anxiety Inventory; SUDS, subjective units of distress; TFEQ, Three Factor Eating Questionnaire; tx, treatment.

Psychotherapy trials for bulimia nervosa. Cognitive Behavior Therapy. CBT focusing on cognitive and behavioral factors that maintain bulimic behaviors is the most widely studied intervention for BN. Eleven trials of various designs delivered CBT either individually or in group format. CBT was compared with interpersonal psychotherapy (IPT),^269,^ ^276,^ ^287,^ ^288^ with supportive expressive therapy,^278^ with nutritional counseling,^280,^ ^283^ and with exercise.^283^ One study compared individually with group-administered CBT.^273^ Several studies dismantled CBT by comparing complete CBT with behavioral therapy (BT) in the absence of a cognitive component,^276^ by comparing cognitive therapy only with exposure with response prevention only,^274^ and by exploring the additive efficacy of exposure with response prevention grafted onto a basis of cognitive therapy.^271^ Exposure with response prevention is defined as exposing individuals to their high-risk cues (e.g., prebinge cues or prepurge cues) and then preventing the response (e.g., binge eating or purging) until the urge to engage in the behavior subsides.

In comparisons of individually administered CBT and IPT tailored for BN, CBT was associated with a significantly greater probability of remission than IPT^269^ and with greater decreases in vomiting and restraint^269,^ ^276^ and binge eating^269^ at the end of treatment. In one study at 1-year followup, these differences were no longer apparent.^276^ Neither CBT nor IPT led to greater improvements in mood or changes in weight. Changes in dietary restraint and in eating self-efficacy mediated change in binge and purge frequency.^288^ Being in the precontemplation stage of change was associated with failure to achieve remission at the end of treatment.^268^

When administered in group format, differences between CBT and IPT were less clear. Both group-administered treatments led to significantly greater decreases than waiting list on days binged, psychological features of the eating disorder, disinhibition, and restraint, with no differences observed between the active therapies.^287^

When compared directly, few differences emerged between group and individual administration of CBT. Both showed decreases in objective and subjective binge episodes, vomiting, laxative use, overexercise and EDI bulimia, drive for thinness, and body dissatisfaction subscale scores.^273^ Group CBT was associated with greater decreases in anxiety; individual CBT was associated with significantly higher rates of abstinence. From a cost-effectiveness perspective, the study concluded that group CBT was more economical, given the similarity of outcomes.

In the dismantling studies, which attempted to parse out the effects of various components of CBT, the cognitive component emerged as critical to therapeutic outcome. Complete CBT led to better eating-related outcomes than BT,^276^ to lower relapse than exposure with response prevention only,^274^ and to greater abstinence than a self-monitoring only intervention.^266^

Two studies examined the additive efficacy of exposure with response prevention. Agras and colleagues found no additive benefit of exposure to CBT.^266^ Bulik et al. first treated all patients with a core of cognitive therapy and then explored the added efficacy of three augmentation strategies: exposure with response prevention to prebinge cues, exposure with response prevention to prepurge cues, and a relaxation therapy control.^270^ They found no evidence that either exposure treatment led to greater improvement in binge eating and vomiting than the relaxation control.

In other comparisons, cognitive therapy performed better than support only; adding a cognitive component to nutritional counseling led to a significantly greater decrease in drive for thinness than nutritional therapy alone.^280^ CBT was superior to nutritional counseling alone in improving core binge eating, vomiting, laxative use, and body dissatisfaction. CBT also led to significantly greater decreases than supportive-expressive therapy (a nondirective psychodynamically oriented treatment) in EDI bulimia, EAT scores, food preoccupation, eating concerns, and depression.^278^ Exercise therapy was superior to CBT at 18-month followup in improving drive for thinness, laxative abuse, and binge eating.^283^

Overall, dropout from CBT delivered individually or in group format ranged from 6 percent to 37 percent. Typical rates were about one-quarter of individuals randomized.

Other behavioral interventions. A single study compared nutritional management (focusing on decreasing restraint, detailed nutritional self-monitoring, and stimulus control) to stress management (focusing on decreasing stressors that may trigger binge eating). Both treatments led to significant decreases in binge eating and vomiting; abstinence from binge eating was greater in nutritional management than stress management, although abstinence from vomiting did not differ. Stress management was associated with greater reductions in trait anxiety.^281^

Dialectical behavioral therapy (DBT). DBT focuses on emotional dysregulation as the core problem in BN with symptoms viewed as attempts to manage unpleasant emotional states. A small study showed that patients receiving DBT had significantly greater decreases in binge eating and purging than did those on a waiting list and that abstinence was greater at the end of treatment in the DBT than in the waiting list group.^282^

Self-help trials. We present self-help trials for BN in Table 17. In a direct 18-week comparison of guided self-help (manual including visits with nonspecialists in eating disorders to check on progress) with group CBT, both treatments significantly decreased binge eating, vomiting, laxative use, EDI bulimia, drive for thinness and body dissatisfaction.^290^ At 1-year followup, individuals in the self-help group showed greater reductions in vomiting and EDI bulimia. CBT was associated with greater reductions in drive for thinness over the treatment period and at followup. Both treatments significantly improved depression, with no differences between groups at the end of treatment; however, at followup, individuals in the self-help group had lower depression scores. Of those who completed treatment, a significantly greater number of individuals in the self-help group than in the CBT group were in remission for more than 2 weeks at the end of treatment (74 percent versus 44 percent). No significant change was seen in weight, although those in the self-help condition weighed significantly more at 1 year.

Table 17 Results from self-help trials, no medication: bulimia nervosa

Source, Treatment, Setting, and Quality Score | Major Outcome Measures | Significant Change Over Time Within Groups | Significant Differences Between Groups at Endpoint | Significant Differences Between Groups in Change Over Time
Bailer et al., 2004^290^ | Eating:; - Binge frequency; - EDI; - Laxative use; - Meal frequency; - Recovery; - Remittance; - Vomit frequency | No statistics reported. | Higher meal frequency in self-help at post-tx. | Self-help superior to CBT in reducing bulimia symptoms over 18 weeks.
Guided self-help vs. group CBT | Biomarker:; - BMI | | Lower vomit frequency, depressed mood, laxative use, and bulimia symptoms, and higher BMI in self-help, at 1-year FU. | CBT superior to self-help in reducing drive for thinness over tx and FU periods.
Outpatient | Psych:; - BDI
Fair
Carter et al., 2003^291^ | Eating:; - Binge frequency; - EDE; - Exercise frequency; - Purge frequency | Both self-help groups decreased binge and purge frequencies. | No differences on any measures. | CBT-based self-help superior to non-specific self-help and to waiting-list in reducing intense exercising.
CBT-based self-help vs. non-specific self-help vs. waiting-list | Psych:; - BAI; - BDI; - IIP | CBT-based self-help experienced a decrease in intense exercising.
Outpatient
Fair
Durand and King, 2003^292^ | Eating:; - BITE; - Bulimic episodes; - EDE; - Vomit episodes | No statistics reported. | No differences on any measures. | No differences on any measures.
General practice physician- based self-help vs. specialist-based self-help | Psych:; - BDI; - Patient-rated severity
Outpatient
Fair
Thiels et al., 1998^293^ | Eating:; - Binge abstinence; - BITE; - EDE; - ED Awareness Test; - Purge Abstinence | No statistics reported. | Lower BITE scores in guided self-change group. | No differences on any measures.
CBT vs. guided self-change | Biomarker:; - BMI
Outpatient | Psych:; - BDI; - Self-esteem
Fair

BAI, Beck Anxiety Inventory; BDI, Beck Depression Inventory; BITE, Bulimic Investigation Text Edinborough; BMI, Body mass index; CBT, Cognitive Behavioral Therapy; EDE, Eating Disorder Examination; EDI, Eating Disorders Inventory; FU, followup; HDRS, Hamilton Depression Rating Scale [HDRS-17 items, HDRS-21 items]; IIP, Inventory of Interpersonal Problems; Psych, psychiatric and psychological; tx, treatment.

Carter et al. compared CBT-based self-help^302^with nonspecific self-help, focusing on self-assertion for women, with a waiting list control group in a 2-month trial.^291^ Both self-help approaches led to significant decreases in objective binge episodes and purging; the waiting list did not. CBT-based self-help was associated with greater reductions in reducing intense exercise than nonspecific self-help or waiting list. No change in depression was observed. Abstinence and weight values were not reported.

To understand the feasibility and efficacy of self-help delivered in general practitioner (GP) offices, Durand and King compared GP-supported CBT-based self-help^303^ with specialist outpatient treatment.^292^ The duration of treatment was at the clinician's discretion. Patients in both groups reported significant decreases in scores on the Bulimic Investigation Test Edinburgh (BITE) and Eating Disorders Examination (EDE) total; however, binge eating and vomiting did not drop significantly. Both groups reported significant decreases in depression, but no treatment was superior. Weight change was not reported. Drop-out rates were similar across groups (24 percent in the GP group and 18 percent in specialist care).

A German study by Thiels et al. compared 16 weeks of CBT with guided self-change using a manual.^293^ Guided self-change included 16 sessions with a therapist encouraging use of the manual and addressing motivation, obstacles, and emergent crises. Significant decreases occurred in overeating, vomiting, BITE scores, and EAT scores for both groups combined. Only on BITE scores did the CBT group perform significantly better than the guided self-change group. Depression dropped in both treatment groups with no significant differences between groups. Dropout was 13 percent in CBT and 29 percent in guided self-change.

Additional interventions for bulimia nervosa. We present other interventions for BN in Table 18. Three studies explored interventions that did not fit into our classification scheme: active light (such as that used to treat seasonal affective disorder), crisis prevention, and guided imagery.

Table 18 Results from other trials: bulimia nervosa

Source, Treatment, Setting, and Quality Score | Major Outcome Measures | Significant Change Over Time Within Groups | Significant Differences Between Groups at Endpoint | Significant Differences Between Groups in Change Over Time
Braun et al., 1999^295^ | Eating:; - Binge frequency; - Meal frequency; - Purge frequency; - Seasonal patterns assessment questionnaire; - YBC-EDS | No statistics reported. | No differences on any measures. | Bright light superior to dim light (placebo) in reducing binge frequency over 3 week tx.
Bright light therapy vs. dim light/placebo | Psych:; - BDI; - HAM-D
Outpatient
Fair
Mitchell et al., 2004^297^ | Eating:; - Resumption of bingeing and/or purging after period of abstinence | No differences on any measures. | No differences on any measures. | No differences on any measures.
Crisis prevention vs. usual follow-up
Outpatient
Fair
Esplen et al., 1998^296^ | Eating:; - Abstinence; - Binge frequency; - EAT-26; - EDI; - Purge frequency | No statistics reported. | Higher abstinence rate in guided imagery compared to control group. | Guided imagery superior to control in reducing binge and purge frequencies, drive for thinness, bulimia symptoms, and body dissatisfaction over 6 week tx period.
Guided imagery vs. control (eating behavior journaling therapies)
Outpatient
Fair

BDI, Beck Depression Inventory; EAT, Eating Attitudes Test (EAT-26 items); EDI, Eating Disorders Inventory; HAM-D, Hamilton Depression Rating Scale; Psych, psychiatric and psychological; tx, treatment; YBC-EDS, Yale-Brown-Cornell Eating Disorder Scale

Light therapy. In a small 8-week trial of 10,000 lux white light (active light) versus 50 lux red light (control), individuals in the active light group showed significantly greater decreases in binge eating than individuals in the control group.^295^ Mood improved in both groups but no additional differences were observed for any other eating disorder, psychological, or biomarker outcome. The investigators did not provide long-term follow-up data. Given the size of this trial and the absence of followup, results should be viewed as preliminary.

Crisis prevention. Individuals who were abstinent after a trial of CBT were randomized to either a crisis prevention group in which they were able to contact their clinician to receive up to eight additional visits over 17 months if they felt their condition was deteriorating or a control follow-up-only group.^297^ The percentage of individuals who resumed binge eating and purging did not differ over the 17-month interval; however, none of the individuals in the crisis prevention group used any of their available calls despite the reappearance of bulimic symptoms.

Guided imagery. Esplen et al. conducted a 6-week trial of patients in a guided imagery group and a control journaling group.^296^ Guided imagery was based on developing self-comforting in BN.^304^ Guided imagery led to a significantly greater decrease in measures of binge eating, purging, EDI bulimia, drive for thinness, and body dissatisfaction. At the end of treatment, 21 percent of individuals in guided imagery and no individuals in the control condition were abstinent. Drop-out rates were comparable across groups.

Summary of behavioral interventions for bulimia nervosa. A large number of fair- to good-rated trials provide evidence that CBT administered individually or in group format is effective in reducing the core behavioral symptoms of binge eating and purging and psychological features of BN in both the short and the long term. One study suggests that CBT leads to more rapid reduction of symptoms than IPT.^276^ Another suggests that individual CBT confers no advantage over the more economical group CBT approach;^273^ although this finding is important for service delivery, it requires replication. The cognitive component of CBT appears to be the active ingredient for change, as behavioral interventions alone are not as effective.^274,^ ^276^ Exposure with response prevention, either alone or as an added component to a core of cognitive therapy, offers no additional therapeutic advantage to basic CBT.^270,^ ^272,^ ^274^

Adding a cognitive component to nutritional intervention led to greater effectiveness in one study,^280^ and CBT led to better outcomes than a psychodynamically oriented supportive-expressive therapy.^278^ Preliminary evidence suggests that DBT is effective and worth additional study for the treatment of BN.^282^

Four studies provided mixed evidence regarding the efficacy of self-help methods for BN. One German and one Austrian study provide support for guided self-help in comparison to group CBT^290^ and individually administered CBT.^293^ The nature of the self-help approach (CBT oriented versus nonspecific) did not lead to different outcomes.^291^ Preliminary evidence from the United Kingdom indicates that GPs can successfully deliver self-help.^292^ No self-help trials conducted in the United States met our inclusion criteria. Overall, especially in the absence of control conditions, few conclusions can be drawn regarding the efficacy of self-help approaches for BN. Moreover, the term self-help must be considered carefully as many of the interventions labeled self-help included considerable contact with providers.

One report yielded preliminary evidence for treating BN with light leading to some short-term decreases in binge eating.^295^ One study provided some support for guided imagery compared to journaling, although long-term maintenance of treatment effects is unknown.^296^ Crisis prevention approaches do not appear to be effective in the treatment of BN, based on one study, as patients do not avail themselves of the opportunity to contact their therapists when symptoms reemerge.^297^

## Key Question 2: Harms of Treatment for Bulimia Nervosa

Table 19 presents adverse events associated with treatments for BN. As reported in Chapter 3, harms from second-generation antidepressants include the following: for fluoxetine, insomnia, nausea, asthenia, tremor, dizziness, rhinitis, sweating, urinary frequency, and sexual dysfunction; for fluvoxamine, nausea, dizziness and drowsiness.^243^ Adverse events associated with second-generation antidepressants in BN appear to be consistent with those observed in other disorders.^253^

Table 19 Adverse events reported: bulimia nervosa trials

Intervention | Adverse Event *†
Medication Trials
Fluoxetine vs. placebo^244^ | Fluoxetine group: Insomnia, nausea, and shakiness significantly more common
| Placebo group: depression more common
Fluoxetine vs. placebo^248^ | Fluoxetine: significantly more trembling than placebo
Fluoxetine 60mg (F60) vs. fluoxetine 20mg (F20) vs. placebo (PL)^249^ | Side effects by treatment group:
| Insomnia: F60 (30); F20 (23); PL (10); (P < 0.001)
| Nausea: F60 (28); F20 (20); PL (14); (P = 0.021)
| Asthenia: F60 (23); F20 (16); PL (11); (P = 0.039)
| Tremor: F60 (12); F20 (4); PL (0); (P < 0.001)
| Sweating: F60(7); F20 (4); PL (1); (P = 0.036)
| Urinary frequency: F60 (5); F20 (0); PL (2); (P = 0.012)
| Palpitation: F60(5); F20(1); PL(1); (P = 0.017)
| Yawn: F60 (5); F20(1); PL(1); (P = 0.017)
| Mydriasis: F60 (3); F20 (0); PL(0); (P = 0.018)
| Vasodilation: F60(1); F20 (4); PL (0); (P = 0.029)
Fluoxetine (F) vs. placebo (PL)^250^ | Side effects by treatment group:
| Insomnia: F (102); PL (19); (P < 0.05)
| Nausea: F (90); PL(13); (P < 0.001)
| Asthenia, F (63); PL (7); (P < 0.001)
| Anxiety: F (52); PL (9); (P < 0.05)
| Tremor: F (42); PL (2); (P < 0.001)
| Dizziness: F (37); PL (4); (P < 0.05)
| Yawning, F (36); PL (0); (P < 0.001)
| Sweating: F (28); PL (2); (P < 0.05)
| Decreased libido: F (19); PL (1); (P < 0.05)
| Depression: F (30); PL (19); (P < 0.05)
| Myalgia: F (14); PL (12); (P < 0.05)
| Emotional lability: F (8); PL (8); (P < 0.05)
| Conjunctivitis: F (1); PL (3); (P < 0.05)
Fluoxetine vs. placebo^252^ | Fluoxetine: hand tremor (5)
| Placebo: Palpitations (1)
Fluoxetine vs. placebo^254^ | Fluoxetine: rhinitis (24)
| Placebo: rhinitis (12); (P < 0.04)
Fluvoxamine vs. placebo^247,299^ | Fluvoxamine: nausea, dizziness and drowsiness significantly more common in patients receiving fluvoxamine
| Fluvoxamine: Drop outs due to general side effects (8)
Trazodone vs placebo^255^ | Trazodone significantly more dizziness and drowsiness than placebo
Topiramate vs. placebo^251,259^ | Topiramate: Dropouts (1) facial rash and irritability
| Placebo: Dropouts (2)
Brofaromine vs. placebo^253^ | Brofaromine: nausea (2); sleep disturbance, nausea, dizziness
| Placebo: headache (1); dry mouth, nausea
Ondansetron vs. placebo^246^ | No adverse events observed
Desipramine vs. placebo^257^ | NR
Medication plus Behavioral Intervention Trials
Fluoxetine vs. individual CBT vs. fluoxetine and individual CBT^261^ | Fluoxetine: Dropouts due to side effects (4)
| Fluoxetine plus CBT: Dropouts due to side effects (2)
| Nature of side effects NR
Fluoxetine vs. manual based self-help^262^ | NR
Fluoxetine plus guided self-help vs. placebo plus guided self help vs. fluoxetine vs. placebo^265^ | NR
Desipramine 16 wks vs. despipramine 24 wks vs. desipramine 16 wks plus CBT vs. CBT only^260,300^ | NR
Interpersonal psychotherapy vs. antidepressant (fluoxetine replaced by desipramine if no effect) in CBT nonresponders^263^ | NR
CBT plus medication vs. CBT plus placebo vs. Supportive therapy plus med vs. supportive therapy plus placebo^264,301^ | NR
Behavioral Intervention Trials
CBT vs. Interpersonal psychotherapy^269^ | 9 withdrawn from treatment: 7 severe depression, 1 acute onset of panic disorder
CBT vs. exposure response prevention^274^ | NR
CBT vs. Behavior therapy vs. interpersonal psychotherapy^267,^,^276,277^ | Behavior therapy: Drop out (1) severe weight loss
Group CBT vs. group Interpersonal psychotherapy vs. waiting list control^287^ | NR
CBT vs. interpersonal psychotherapy^288^ | NR
CBT vs. supportive-expressive therapy^278^ | NR
Cognitive therapy vs. nutritional therapy^280^ | NR
CBT vs. physical exercise vs. nutritional counseling^283^ | Exercise: injury (1)
Individual CBT vs. Group CBT^273^ | Alcohol abuse (2), AN (1), visual hallucinations (1). No indication of which group these participants were in.
CBT vs. CBT plus response prevention vs. self-monitoring vs. waiting-list^266^ | NR
CBT plus exposure with response prevention to pre-binge cues vs. CBT plus exposure to response prevention with pre-purge cues vs. CBT plus relaxation training^270^–^272^ | NR
Nutritional management vs. stress management^281^ | NR
DBT vs. waiting list^282^ | NR
Self-help Trials
Guided self-help vs. group CBT^290^ | NR
Self-help manual vs. waiting list control^291^ | NR
Self-help intervention vs. clinic intervention^292^ | NR
CBT vs. guided self-change sessions^293^ | NR
Other Trials
Active light vs. placebo dim light^295^
Crisis prevention vs. follow up^297^
Guided imagery vs. control^296^

CBT, cognitive behavioral therapy; DBT, dialectical behavioral therapy; NR: not reported

* If no numbers appear in parentheses, authors had only listed adverse events but not reported the number of cases.

† P values indicate differences between groups; they are reported with they are provided by the author.

Side effects of MAOI administration were nausea, sleep disturbance, and dizziness. No hypertensive crises were reported, although this danger should always be considered in patients who experience uncontrollable eating episodes.^121^

## Key Question 3: Factors Associated With Treatment Efficacy

### Medication Trials

A few medication trials for BN explored factors associated with outcome. Walsh et al. reported that patients with greater concern for body shape and weight and longer duration of illness had more favorable treatment responses.^257^ The Fluoxetine BN Collaborative Study group found that heavier patients had higher response rates in each treatment group.^249^

### Behavioral Intervention Trials

Behavioral interventions in BN provided better and reasonably consistent information about factors associated with treatment response. Several investigators reported two factors as associated with poor outcome: high frequency of binge eating^270,^ ^272,^ ^274,^ ^298,^ ^301^ and longer duration of illness.^274,^ ^298^

Evidence was mixed or contradictory for other factors. Higher body dissatisfaction was associated with both poorer^270^ and better outcome.^277^ With respect to weight, a history of obesity was reported as a positive prognostic indicator^270^ and as a predictor of dropout.^278^ Better outcomes or more rapid response were associated with higher baseline depression, lower severity of binge eating,^287^ and greater attitudinal disturbance at baseline.^277^ Positive response was reported to be associated with a history of obesity, a history of alcoholism, and high scores for self-directedness^270^ and self-control.^280^ Poorer outcomes were associated with greater food restriction, higher depression, higher drive for thinness and bulimia scores on the EDI, and greater cue reactivity,^270^ low self-esteem,^277^ and precontemplation stage of change.^268^

### Self-help Trials

Factors associated with positive response to self help included higher EDI perfectionism scores, higher Dimensional Assessment of Personality Pathology (DAPP) compulsivity scores, higher DAPP intimacy problem scores, and lower cognitive behavior knowledge scores.^291^

### Other Interventions Trials

Higher soothing receptivity and ability to tolerate aloneness were associated with more positive outcomes in guided imagery therapy.^296^

## Key Question 4: Treatment Efficacy by Subgroups

The total number of individuals enrolled in the 18 trials of drugs or drug plus behavioral interventions was 1,941. Of those 67 were men. No studies reported differential outcome by age. Thirteen studies failed to report the race or ethnicity of participants. Of those that did, 793 participants were identified as white, 57 as nonwhite, 33 as Asian, 12 as Hispanic American, and eight as African American. Of the 18 trials, 12 were conducted in the United States. No study analyzed results separately by sex or by race or ethnicity. Based on these results, we conclude that no information exists regarding differential efficacy of medication only or combined medication plus behavioral interventions for BN by sex, gender, age, race, ethnicity, or cultural group.

The total number of individuals enrolled in behavioral intervention or other intervention trials was 1,462. Of those, two were men. Of the 18 trials, 14 failed to reported race or ethnicity of participants. From the remaining four trials, 410 subjects were identified as white; 22 as nonwhite; 28 Hispanic-American; 26 as Asian; Maori or Pacific Islander; 19 as African-American or Afro-Caribbean; and one as Native American. In no instance did the investigators analyze results separately by race or ethnic group. No data exist regarding differential efficacy of behavioral interventions for BN by sex, gender, age, race, ethnicity, or cultural group.