# Results: Anorexia Nervosa

This chapter presents results of our literature search and our findings for the key questions (KQs) regarding treatment for anorexia nervosa (AN). We examine evidence for the efficacy of various treatments or combinations of treatments for AN (KQ 1), harms associated with the treatment or combination of treatments for AN (KQ 2), factors associated with the efficacy of treatment for AN (KQ 3), and whether the efficacy of treatment for AN differs by sex, gender, age, race, ethnicity, or cultural groups (KQ 4).

We report first on specific details about the yields of the literature searches and characteristics of the studies, then on literature pertaining to treatment (KQs 1 to 4). For each included study, detailed evidence tables appear in Appendix C *. We report first on medication trials (Evidence Table 1), then combined medication and behavioral interventions (Evidence Table 2), then behavioral interventions separately for adults (Evidence Table 3), and adolescents (Evidence Table 4). We distinguish between behavioral interventions for adolescents and adults in order to address age differences (KQ 4) as clearly as possible, given the current state of the literature. Within each evidence table, studies are listed alphabetically by author.

* Appendixes cited in this report are provided electronically athttp://www.ahrq.gov/downloads/pub/evidence/pdf/eatingdisorders/eatdis.pdf.

## Overview of Included Studies

We identified 32 studies published in 35 articles addressing treatment efficacy for AN; of these 15 were medication trials. We were unable to categorize medication studies into adolescent and adult trials given the paucity of medication trials focusing on adolescents.

We rated two medication trials as good,^206^ six as fair,^207^–^213^ and seven as poor (not discussed further).^124,^ ^214^–^219^ Of the studies judged fair or good, the medications studied included second-generation antidepressants,^206,^ ^207^ tricyclic antidepressants,^208,^ ^209^ nutritional supplements,^213^ and hormones.^210^–^212^ Study designs included medication versus placebo (six trials), medication A versus medication B versus placebo (one), and medication versus waiting list or nonmedication control (one).

Eighteen of the 32 studies were behavioral intervention trials. In this report behavioral interventions refer to all forms of psychotherapy including cognitive, supportive, dynamic, family, individual, and group. One trial was of therapeutic warming.^220^ We rated two of these trials as good,^221,^ ^222^ nine as fair,^223^–^231^ and six as poor (not discussed further).^220,^ ^232^–^236^ Of the 11 trials reviewed here, six were conducted among adults and five among adolescents. Behavioral interventions studied include cognitive behavioral therapy (CBT),^223^–^225^ cognitive analytic therapy (CAT),^226^ focal psychoanalytic therapy,^228^ and various forms of family therapy.^221,^ ^222,^ ^229^–^231,^ ^237^ The behavioral intervention trials used two designs: psychotherapy A versus psychotherapy B, and psychotherapy A versus psychotherapy B versus control.

We do not discuss studies with a quality rating of “poor” further; reasons these studies received this rating are presented in Table 6. While studies were not lacking in all areas, the most frequent deficiencies across studies contributing to a poor rating include the following: a fatal flaw in the approach to randomization or the approach not being described; investigators and outcome assessors not being blinded to study arm or their blinding status not being described; adverse events not being reported; the statistical analysis not including or not reporting whether a power analysis was conducted; a lack of necessary controls for confounding or results not presented using an intention-to-treat approach; and sources of funding not being stated.

Table 6 Reasons for poor quality ratings and number of trials with poor ratings: anorexia nervosa

Reasons Contributing to Poor Ratings | Types of Intervention, Number of Times Flaw Was Detected, and Citations
Research Aim
Hypothesis not clearly described | Medication-only trials: 0
| Behavioral intervention trials (adults): 0
| Behavioral intervention trials (adolescents): 0
Study Population
Characteristics not clearly described | Medication-only trials: 0
| Behavioral intervention trials (adults): 0
| Behavioral intervention trials (adolescents): 0
No specific inclusion or exclusion criteria | Medication-only trials: 1^214^
| Behavioral intervention trials (adults): 1^233^
| Behavioral intervention trials (adolescents): 0
Randomization
Protections against influence not in place | Medication-only trials: 6^124,^,^214–^,^216,^,^218,219^
| Behavioral intervention trials (adults): 1^233^
| Behavioral intervention trials (adolescents): 0
Approach not described | Medication-only trial: 6^124,214^–^216,^,^218,219^
| Behavioral intervention trials (adults): 1^233^
| Behavioral intervention trials (adolescents): 1^236^
Whether randomization had a fatal flaw not known | Medication-only trials: 6^124,214^–^216,^,^218,219^
| Behavioral intervention trials (adults): 1^233^
| Behavioral intervention trials (adolescents): 2^235,236^
Comparison group(s) not similar at baseline | Medication-only trials: 3^214,^,^215,219^
| Behavioral intervention trials (adults): 0
| Behavioral intervention trials (adolescents): 1^236^
Blinding
Study subjects | Medication-only trials: 4^215^–^217,219^
| Behavioral intervention trials (adults): N/A
| Behavioral intervention trials (adolescents): N/A
Investigators | Medication-only trials: 6^124,215^–^219^
| Behavioral intervention trials (adults): 1^220^
| Behavioral intervention trials (adolescents): 0
Outcomes assessors | Medication-only trials: 6^124,215^–^219^
| Behavioral intervention trials (adults): 3^220,^,^233,234^
| Behavioral intervention trials (adolescents): 2^235,236^
Interventions
Interventions not clearly described | Medication-only trials: 0
| Behavioral intervention trials (adults): 0
| Behavioral intervention trials (adolescents): 0
No reliable measurement of patient compliance | Medication-only trials: 5^214^–^217,219^
| Behavioral intervention trials (adults): 1^220^
| Behavioral intervention trials (adolescents): 1^235^
Outcomes
Results not clearly described | Medication-only trials: 0
| Behavioral intervention trials (adults): 2^220,233^
| Behavioral intervention trials (adolescents): 0
Adverse events not reported | Medication-only trials: 3^214,^,^215,217^
| Behavioral intervention trials (adults): 2^233,234^
| Behavioral intervention trials (adolescents): 1^235^
Statistical Analysis
Statistics inappropriate | Medication-only trials: 0
| Behavioral intervention trials (adults): 3^220,^,^232,233^
| Behavioral intervention trials (adolescents): 0
No controls for confounding (if needed) | Medication-only trials: 3^214,^,^218,219^
| Behavioral intervention trials (adults): 2^232,233^
| Behavioral intervention trials (adolescents): 2^235,236^
Intention-to-treat analysis not used | Medication-only trials: 5^214,^,^215,217^–^219^
| Behavioral intervention trials (adults): 2^220,233^
| Behavioral intervention trials (adolescents): 2^235,236^
Power analysis not done or not reported | Medication-only trials: 7^124,214^–^219^
| Behavioral intervention trials (adults): 4^220,232^–^234^
| Behavioral intervention trials (adolescents): 1^235^
Results
Loss to followup 26% or higher or not reported | Medication-only trials: 2^214,215^
| Behavioral intervention trials (adults): 1^233^
| Behavioral intervention trials (adolescents): 0
Differential loss to followup 15% or higher or not reported | Medication-only trials: 1^214,215^
| Behavioral intervention trials (adults): 3^220,^,^233,234^
| Behavioral intervention trials (adolescents): 1^236^
Outcome measures not standard, reliable, or valid in all groups | Medication-only trials: 0
| Behavioral intervention trials (adults): 1^220^
| Behavioral intervention trials (adolescents): 0
Discussion
Results do not support conclusions, taking possible biases and limitations into account | Medication-only trials: 0
| Behavioral intervention trials (adults): 0
| Behavioral intervention trials (adolescents): 0
Results not discussed within context of prior research | Medication-only trials: 0
| Behavioral intervention trials (adults): 0
External validity: population not representative of US population relevant to these treatments | Medication-only trials: 3^215,^,^217,218^
| Behavioral intervention trials (adults): 1^220^
| Behavioral intervention trials (adolescents): 0
Funding/sponsorship not reported | Medication-only trials: 6^214^–^219^
| Behavioral intervention trials (adults): 3^220,^,^232,234^
| Behavioral intervention trials (adolescents): 1^235^

N/A, not applicable.

Dropouts are a significant element in the quality of all these trials. Table 7 documents the total sample size and attrition rates in the trials reviewed in this chapter.

Table 7 Dropout rates for randomized controlled trials: anorexia nervosa

Author | Total Enrollment | Total Dropouts | Group 1 Treatment (% dropout) | G2 Treatment (% dropout) | G3 Treatment (% dropout) | G4 Treatment (% dropout)
Medication Trials
Attia et al., 1998^206^ | 33 | 1 (+1 unreliable self-reporter) (3%) | Fluoxetine (NR) | Placebo (NR)
Kaye et al., 2001^207^ | 39 | 26 (66%) | Fluoxetine (16% at 30 days, 47% at 1 year) | Placebo (5% at 30 days, 85% at 1 year)
Biederman et al.,1985^209^ | 25 | 0 (0%) | Amitriptyline (0%) | Placebo (0%)
Halmi et al.,1986^208^ | 72 | 18 (25%) | Amitriptyline (30%) | Cyproheptadine (25%) | Placebo (20%)
Hill, et al., 2000^212^ | 15 | 0 (0%) | Recombinant human growth hormone (0%) | Placebo (0%)
Klibanski et al., 1995^210^ | 48 | 4 (8%) | Estrogen/progestin (14%) | Control (4%)
Miller, Grieco, and Klibanski 2005^211^ | 38 | 5 (13%) | Testosterone (NR) | Placebo (NR)
Birmingham, Goldner, and Bakan1994^213^ | 54 | 19 (35%) | Zinc (39%) | Placebo (32%)
Behavioral Intervention Trials (Adult)
Channon et al., 1989^225^ | 24 | 3 (13%) | CBT (0%) | Behavioral treatment (13%) | Control (25%)
McIntosh et al., 2005^224^ | 56 | 21 (38%) | CBT (37%) | Interpersonal psychotherapy (43%) | Nonspecific supportive clinical management (31%)
Pike et al., 2003^223^ | 33 | 3 (9%) | CBT (0%) | Nutritional counseling (20%)
Dare et al., 2001^228^ | 84 | 30 (36%) | Focal psychotherapy (43%) | Family therapy (27%) | Cognitive analytic therapy (41%) | Routine (32%)
Treasure et al., 1995^226^ | 30 | 10 (33%) | Educational behavioral therapy (38%) | Cognitive analytic therapy (29%)
Crisp et al., 1991^227^ and Gowers et al.,1994^238^ | 90 | 17 (19%) | Inpatient (40%) | Outpatient psychotherapy/family therapy/dietary counseling (10%) | Group therapy (15%) | No further treatment (0%)
Behavioral Intervention Trials (Adolescent)
Eisler et al., 2000^221^ | 40 | 4 (10%) | Conjoint family therapy (11%) | Separated family therapy (10%)
Geist et al., 2000^229^ | 25 | 0 (0%) | Family therapy (0%) | Family group psychoeducation (0%)
Russell et al., 1987^231^ and Eisler et al., 1997^239^ | 80 | 28 (35%) | Family therapy (37%) | Individual therapy (33%)
Robin et al., 1994^230^ and Robin, Siegel, and Moye 1995^237^ | 24 | 2 (8%) | Behavioral family systems therapy (8%) | Ego-oriented individual therapy (8%)
Lock et al., 2005^222^ | 86 | 17 (20%) | Long-term treatment (24%) | Short-term treatment (16%)

CBT, cognitive behavioral therapy; NR, not reported.

### Participants

Of the 19 studies rated fair or good, 10 were conducted in the United States, six in the United Kingdom, two in Canada, and one in New Zealand. A total of 891 individuals participated in fair or good clinical trials for AN. One study failed to report sex. From those studies that reported sex, 861 women and 23 men participated. Seventeen studies failed to report ethnicity for participants. Of those that did, 123 participants were identified as white, eight as Asian and three as other ethnicity.

## Key Question 1: Treatment Efficacy

### Medication Trials

Table 8 presents results from medication treatment trials for AN, including treatment aims, setting (inpatient or outpatient), and a summary of outcomes. Similar to text, it is organized by medication class. Of the identified AN trials, eight were randomized controlled double-blind medication trials. Medication trials for AN were most commonly conducted in the context of clinical management or during or following inpatient refeeding. Of these, none reported race or ethnicity of participants, while all but one reported sex of participants; six were conducted in the United States. One study explicitly reported intention-to-treat analyses.^212^ The number of participants in the medication trials ranged from 15 to 72, with the total enrollment for all medication trials being 345. Thus, the average number of patients per study was 23. Based on those studies that reported sex, this includes 319 women and 1 man.

Table 8 Results from medication trials: anorexia nervosa

Source, Treatment, Setting, and Quality Score | Major Outcome Measures | Significant Change Over Time Within Groups | Significant Differences Between Groups at Endpoint | Significant Differences Between Groups in Change Over Time
Attia et al., 1998^206^ | Eating: | Both groups experienced decreased clinician-rated ED symptoms and illness severity, ED concerns, depressed mood, obsessive-compulsive symptoms, and food preoccupation and rituals. Both groups increased percent IBW. | No statistics reported. | No differences on any measures.
Fluoxetine vs. placebo | AN behavior
Inpatient | BSQ
Good | CGI
| EAT
| YBC-EDS
| Biomarker:
| IBW
| Psych:
| BDI
| CGI
| SCL-90
Kaye et al., 2001^207^ | Eating: | Fluoxetine completers experienced decreased anxious and depressed mood and increased percent ABW | No differences on any measures. | No differences on any measures.
Fluoxetine vs. placebo | YBC-EDS
Inpatient and outpatient | Biomarker:
Fair | ABW
| Psych:
| HAM-A
| HDRS
| YBOCS
Biederman et al., 1985^209^ | Eating: | No statistics reported. | No differences on any measures. | No statistics reported.
Amitriptyline vs. placebo | EAT
Inpatient and outpatient | Biomarker:
Fair | Weight
| Psych:
| Global severity
| HSCL
| SADS-C
Halmi et al., 1986^208^ | Eating: | No statistics reported. | Cyproheptadine associated with fewer days to target weight, higher caloric intake, and less depressed mood compared to placebo. | No statistics reported.
Amitriptyline vs. cyproheptadine vs. placebo | Caloric intake | | BN subgroup: amitriptyline associated with improved tx efficacy compared to cyproheptadine; neither drug differed from placebo.
Inpatient | Biomarker: | | For non-BN subgroup: cyproheptadine associated with improved tx efficacy compared to placebo. No other subgroup comparisons were significant.
Fair | Weight
| Psych:
| HAM-D
| BDI
| SCL-90
Hill et al., 2000^212^ | Biomarker: | No statistics reported. | rhGH associated with fewer days to restoration of normal orthostatic response compared to placebo. | No statistics reported.
rhGH vs. placebo | Orthostasis
Inpatient | Weight
Good
Klibanski et al., 1995^210^ | Eating: | No statistics reported. | No differences on any measures. | No differences on any measures.
Estrogen/progestin vs. nonmedication control | Recovery
Outpatient | Remission
Fair | Biomarker:
| Bone density
| Percent Body fat
| Percent IBW
| Weight
Miller et al., 2005^211^ | Biomarker: | No statistics reported. | Testosterone associated with less depressed mood compared to placebo. | Depressed mood increased less in testosterone-treated group.
Testosterone vs. placebo | BMI
Setting unknown | IBW
Fair | Psych:
| BDI
Birmingham et al., 1994^213^ | Biomarker: | No statistics reported. | No differences on any measures. | Zinc superior to placebo in rate of BMI increase.
Zinc vs. placebo | BMI
Inpatient | Percent body fat
Fair | Weight

ABW, average body weight; AN, anorexia nervosa; BDI, Beck Depression Inventory; BMI, body mass index; BN, bulimia nervosa; BSQ, Body Shape Questionnaire; CGI, Clinical Global Impressions; EAT, Eating Attitudes Test; ED, eating disorders; HAM-A, Hamilton Anxiety Inventory; HAM-D, Hamilton Depression Inventory; HDRS, Hamilton Depression Rating Scale; HSCL, Hopkins Symptom Checklist; IBW, ideal body weight; Psych, psychiatric and psychological; rhGH, recombinant human grown hormone; SADS-C, Schedule for Affective Disorders and Schizophrenia-Change Version; SCL-90, (Hopkins) Symptom Checklist; tx, treatment; vs., versus; YBC-EDS, Yale-Brown-Cornell Eating Disorders Scale; YBOCS, Yale-Brown Obsessive-Compulsive scale.

Weight gain is the primary outcome variable in the treatment of AN. Secondary outcomes in this population include reduction of the psychological features of AN (e.g., body dissatisfaction and drive for thinness), reduction of associated behaviors such as overexercising, resumption of menses, and, in the bingeing and purging subtype, decreased binge eating and purging behaviors. Additional psychiatric outcomes include reduction in depression and anxiety.

Second-generation antidepressants. The term “second-generation antidepressants” is commonly used in the psychiatric and pharmacological literature to distinguish newer antidepressants such as selective norepinephrine reuptake inhibitors (SNRIs), selective serotonin reuptake inhibitors (SSRIs), bupropion, nefazodone, and trazodone from traditional or first-generation antidepressants such as tricyclic antidepressants and monoamine oxidase inhibitors. We adopted this term to be consistent in terminology with other research conducted in the area of psychopharmacology.

Fluoxetine. Two trials used fluoxetine at different stages of refeeding in AN patients. In an inpatient study, Attia et al.^206^ randomized 31 females between 16 and 45 years who had achieved weight restoration of at least 65 percent of ideal body weight (IBW) to fluoxetine (60 mg/day) or placebo. The mean BMI at randomization was 15 kg/m^2^. Patients continued to receive psychotherapy. No significant differences emerged between fluoxetine and placebo on weight gain (16 versus 13 pounds), psychological features of eating disorders, or depression or anxiety measures. Three percent of participants dropped out of fluoxetine treatment.

In the second study, patients were randomly assigned to either initiation on fluoxetine or placebo before inpatient discharge with a beginning dosage of 20 mg/day adjusted over 52 weeks to a maximum of 60 mg/day.^207^ The range of weight for all participants at randomization was 76 percent to 100 percent average body weight (ABW) with the majority above 90 percent. Outpatient psychotherapy was permitted. Dropout was considerable. Of 39 individuals randomized, only 13 remained at the 52-week endpoint (47 percent of fluoxetine and 85 percent of placebo). In this small group of completers, fluoxetine was associated with significantly greater weight gain, reduced anxiety, depression, obsessive-compulsive features, and eating-disorder-related symptoms.

Tricyclic antidepressants. Two trials of fair or good quality investigated tricyclic antidepressant medication use. Neither provided strong data supporting the use of these medications in treating AN patients.

Amitriptyline in doses up to 175 mg/day in 25 youth ages 11 to 17 years led to no significant differences in eating, mood, or weight outcomes in comparison to placebo.^209^ No patients dropped out in this trial. Halmi et al. compared amitriptyline (160 mg/day) versus cyproheptadine (32 mg/day) versus placebo in 72 females 13 to 36 years, determined to have AN according to the Diagnostic and Statistical Manual, third edition (DSM III).^208^ Daily caloric intake was significantly higher in cyproheptadine than placebo and significantly fewer days were needed to achieve target weight (in those who did) in both the amitriptyline and cyproheptadine groups, compared with placebo. Drop out was thirty percent in the amitriptyline group, 25 percent in the cyproheptadine group, and 20 percent in the placebo group.

Hormones. Investigators have studied three hormones in the treatment of AN: growth hormone (rGH), testosterone, and estrogen. Three weeks of transdermal testosterone (150 mg or 330 mg) administered to 38 patients with AN ages 18 to 50 led to greater decreases in depression in patients who were depressed at baseline, but differences in weight were not interpretable.^211^ Dropout was 13 percent overall.

Growth hormone (15 mg/kg/day) administered to 14 female and 1 male patient receiving inpatient care for AN led to fewer days to display normal orthostatic heart rate response to a standing challenge among the treatment group than among placebo group.^212^ No patient dropped out of this study.

Klibanski et al. compared estrogen/progesterone (0.625 mg Premarin® or 5 mg Provera® per day) versus nonmedication control in 48 females 16 to 43 years and found no differences between groups on bone density at 6 months.^210^ Dropout was 14 percent in hormone group and 4 percent in the nonmedication group.

Hormone treatment during the acute phase of AN illness does not appear to improve bone density.^210^ Scant, preliminary evidence suggests that rGH leads to faster normalization of orthostatic changes seen in AN^212^and that testosterone improves depression in individuals with AN and depressed mood.^211^

Nutritional supplements. The one study of nutritional supplements was performed in 54 female inpatients older than 15 years with 14 mg/day zinc. It provides preliminary evidence that zinc may increase the rate of increase in BMI.^213^ Dropout was 39 percent in zinc and 32 percent in placebo, suggesting that conclusions from this study must be viewed with great caution.

Summary of drug trials. All eight studies assessing the efficacy of medication interventions on AN examined weight gain; most reported on eating outcomes and some reported on additional symptom change.

Overall, none of the pharmacological interventions for AN had a significant impact on weight gain. Although tricyclic antidepressants may be associated with greater improvement in secondary mood outcomes, this outcome does not appear to be associated with improved weight gain. No trial has been adequately replicated.

Dropout rates for medication studies for AN are substantial, especially in outpatient trials. Conclusions drawn from studies with such high attrition must be reviewed with extreme caution.

Taken together, the literature regarding medication treatments for AN is sparse and inconclusive. The vast majority of studies had small sample sizes and rarely had adequate statistical power to allow for definitive conclusions. Many studies examined patients who were receiving additional treatments in conjunction with the study medication, including psychological interventions and concurrent pharmacological treatments. Some of these studies examined patients who were in inpatient settings, thus limiting generalizability to outpatient treatment. Only one conducted intention-to-treat analyses; the remaining studies reported completer analyses only. With one exception,^209^ no medication trials have focused on adolescent patients. Because followup was limited, assessing longer-term impact of interventions on such outcomes as bone density was impossible. Finally, only one male participated in any of these studies, thereby making it impossible to draw any conclusions about the pharmacological treatment of AN in boys and men.

### Behavioral Intervention Trials

Of the 11 behavior trials rated good or fair (Tables 9 and 10), four focused solely on adolescents (mean ages 14 to 15), six focused solely on adults (approximately 18 years and older), and one combined adolescent and adult patients. Of the 11 trials, four were conducted in the United States. We present behavioral interventions for adults with AN in Table 9.

Table 9 Results from behavioral intervention trials in adults: anorexia nervosa

Source, Treatment, Setting, and Quality Score | Major Outcome Measures | Significant Change Over Time Within Groups | Significant Differences Between Groups at Endpoint | Significant Differences Between Groups in Change Over Time
Channon et al., 1989^225^ | Eating: | No statistics reported. | At 6-month FU, CBT associated with better psychosexual functioning than BT and BT was associated with greater improvement in menstrual functioning than CBT. | No statistics reported.
CBT vs. BT vs. ‘Usual care’ control | EDI | | At 1-year FU, the BT group scored better than the CBT group on preferred weight. CBT and BT combined were associated with greater improvements on nutritional functioning than the control group. The control group showed greater improvements on drive for thinness than the combined CBT and BT groups.
Outpatient | M-R scale
Fair | Biomarker:
| BMI
| M-R scale
| Psych:
| BDI
| MOCI
| M-R scale
McIntosh et al., 2005^224^ | Eating: | | Compared to IPT, NSCM associated with higher likelihood of ‘good’ global outcome. | NSCM superior to IPT in improving global functioning and eating restraint over 20 weeks.
CBT vs. IPT vs. NSCM | EDE | | | NSCM superior to CBT in improving global functioning over 20 weeks.
Outpatient | EDI | | | CBT superior to IPT in improving eating restraint over 20 weeks.
Fair | Biomarker:
| BMI
| Percent body fat
| Weight
| Psych:
| GAF
| HDRS
Pike et al., 2003^223^ | Eating: | No statistics reported. | Compared to nutrition counseling, CBT associated with lower percentage tx failures, higher percentage ‘good’ outcome, and longer time (weeks) to relapse. | No statistics reported.
CBT vs. nutritional counseling | Recovery
Outpatient | Relapse
Fair | Tx failure
| M-R scale
Dare et al., 2001^228^ | Eating: | No statistics reported. | At 1-year FU, compared to routine tx, focal and family tx associated with higher weight; also, higher percentage of patients in focal and family tx were recovered or significantly improved (i.e., > 85% IBW, no/few menstrual or BN symptoms). | No statistics reported.
CAT vs. focal vs. family vs. ‘routine’ therapy | M-R scale
Outpatient | Recovery
Fair | Biomarker:
| BMI
| Percent ABW
| M-R scale
| Psych:
| M-R scale
Treasure et al., 1995^226^ | Eating: | No statistics reported. | Compared to EBT, CAT associated with higher self-rating of improvement. | No statistics reported.
CAT vs. EBT | M-R scales
Outpatient | Biomarker:
Fair | BMI
| Weight
| Psych:
| M-R scales
| Self progress scale
Crisp et al., 1991^227^ and Gowers et al., 1994^238^ | Eating: | At 1-year FU, global score and menstruation improved in all 4 groups, nutrition score improved in 3 active tx groups, and mental state improved in outpatient family/diet counseling group. | Compared to ‘no formal tx’, outpatient family/diet counseling associated with higher weight and BMI at 1- and 2-year FU. | Compared to ‘no formal tx,’ weight increased more at 1-year FU in all 3 active groups.
Inpatient tx vs. outpatient individual and family therapy and dietary counseling vs. group therapy vs. no formal tx | M-R scale | At 2-year FU, mental state improved in outpatient family/diet counseling; global score, menstruation, and nutrition improved in groups that received outpatient family/diet counseling and no formal tx. | | Weight increased more at 2-year FU in outpatient family/diet counseling compared to ‘no formal tx’ group.
Inpatient and outpatient | Remission
Fair | Biomarker:
| BMI
| M-R scale
| Weight
| Psych:
| M-R scale

ABW, average body weight; BDI, Beck Depression Inventory; BMI, body mass index; BT, behavioral therapy; CAT, cognitive-analytic therapy; CBT, cognitive behavioral therapy; EBT, educational behavioral therapy; EDE, Eating Disorders Examination; EDI, Eating Disorders Inventory (EDI-2, Garner, 1991); FU, follow-up; GAF, Global Assessment of Functioning [DSM-IV]; HDRS, Hamilton Depression Rating Scale; IBW, ideal body weight; IPT, interpersonal therapy; MOCI, Maudsley Obsessional Compulsive Index; M-R, Morgan and Russell; NSCM, nonspecific supported clinical management, Psych, psychiatric and psychological; pt, patients; Tx, treatment, vs., versus.

Table 10 Results from behavioral intervention trials in adolescents only and adolescents and adults combined: anorexia nervosa

Source, Treatment, Setting, and Quality Score | Major Outcome Measures | Significant Change Over Time Within Groups | Significant Differences Between Groups at Endpoint | Significant Differences Between Groups in Change Over Time
Eisler et al., 2000^221^ | Eating: | No statistics reported. | No statistics reported. | CFT superior to SFT in reducing ED-related traits, depression, and obsessionality.
CFT vs. SFT | Bulimic symptoms
Outpatient | EAT
Good | EDI
| Biomarker:
| Percent ABW
| BMI
| Weight
| Psych:
| MOCI
| SMFQ
| Depression
| Obsessionality
Geist et al., 2000^229^ | Eating: | No statistics reported. | No differences on any measures. | No differences on any measures.
Family therapy vs. family group psycho-education | EDI
Inpatient | Biomarker:
Fair | Percent IBW
| Psych:
| BSI
| CDI
| FAM III
Russell et al., 1987^231^ and Eisler et al., 1997^239^ | Eating: | No statistics reported. | No statistics reported. | Among early onset, less chronic AN patients, family therapy superior to individual therapy in improving nutritional status, menstrual and psychosexual function, and weight over 1 year tx; family therapy also more likely associated with a ‘good’ outcome over 1-year tx and 5-year FU.
Family therapy vs. individual therapy | M-R scales
Outpatient | Readmit rate
Fair | Biomarker:
| Percent ABW
| M-R scales
| Weight
| Psych:
| M-R scales
Robin et al., 1994^230^ and Robin et al., 1995^237^ | Eating: | No statistics reported. | No differences on any measures. | BFST superior to EOIT in increasing BMI to post-tx and 1-year FU, and in improving mother's positive communication at FU.
BFST vs. EOIT | EAT
Outpatient and inpatient | EDI
Fair | Eating conflict
| Biomarker:
| BMI
| Weight
| Menstruation
| Psych:
| BDI
| BSQ
| PARQ
| IBC
Lock et al., 2005^222^ | Eating: | No differences on any measures. | No differences on any measures. | No differences on any measures among those with most severe YBC-EDS symptoms.
Long-term vs. short-term family therapy | EDE | | | Longer-term tx associated with better BMI outcome in those with most severe ED symptoms, and with better EDE global outcome in those with non-intact families.
Outpatient | YBC-EDS
Good | Biomarker:
| BMI
| Weight

ABW, average body weight; AN, anorexia nervosa; BDI, Beck Depression Inventory; BFST, behavioral family systems therapy; BMI, body mass index; BSI, Brief Symptom Inventory; BSQ, Body Shape Questionnaire; CDI, Children's Depression Inventory; CFT, conjoint family therapy; EAT, Eating Attitudes Test; ED, eating disorders; EDE, Eating Disorders Examination; EDI, Eating Disorders Inventory; EOIT, ego-oriented individual therapy; FAM-III, Family Assessment Measure; FU, follow-up; IBC, Interaction Behavior Code; IBW, ideal body weight; MOCI, Maudsley Obsessional Compulsive Index; M-R, Morgan and Russell; PARQ, Parent Adolescent Relationship Questionnaire; Psych, psychiatric and psychological; SFT, separated family therapy; SMFQ, Short Mood and Feeling Questionnaire; tx, treatment; vs., versus; YBC-EDS, Yale-Brown-Cornell Eating Disorders Scale.

Behavioral interventions for adults with anorexia nervosa. In the psychotherapy trials for adults only and the combined adult and adolescent trials, investigators tested CBT (three trials), various types of nonspecific therapy (three), family therapies (two), CAT (two), dietary counseling (one), interpersonal psychotherapy (IPT) (one), behavioral therapy (BT) (one), and focal analytic therapy (one).

Cognitive behavioral therapy. CBT studies generally used a form of therapy tailored to AN that focused on cognitive and behavioral features associated with the maintenance of eating pathology. Of the three CBT studies, one followed inpatient weight restoration^223^ and two were done in the underweight state.^224,^ ^225^ CBT significantly reduced relapse risk and increased the likelihood of good outcome compared to nutritional counseling based on nutritional education and food exchanges after inpatient weight restoration.^223^ Of those receiving CBT, a greater number of individuals with good outcomes were also receiving antidepressant medication.

One study of underweight AN outpatients compared CBT with IPT and nonspecific supportive clinical management (NSCM).^224^ IPT in the treatment of AN is based on IPT used for the treatment of depression^240^ and BN;^241^ it focuses on one of four interpersonal problem areas: interpersonal disputes, role transitions, grief, or interpersonal deficits. NSCM was designed for this study to mimic the type of treatment an individual could receive in the community from a provider familiar with the treatment of ED and incorporates elements of sound clinical management and supportive psychotherapy. In an intention-to-treat analysis, NSCM performed significantly better than IPT in producing global good outcome ratings; CBT outcomes fell in between and were not significantly different from the other two outcomes.^224^ The second study compared CBT with BT and a control group for 6 months.^225^ At 12-month followup, CBT showed no advantage over BT or control in eating, mood, or weight outcomes.

On the basis of one trial, preliminary evidence suggests that CBT delivered after weight restoration may help to decrease relapse. In contrast, when delivered during the acute phase of the illness, CBT does not appear to offer significant advantage over NSCM, which did offer advantage over IPT. No evidence suggests that nutritional counseling alone is efficacious in the treatment of AN.

Cognitive analytic therapy (CAT). The two studies that utilized CAT, a treatment which integrates psychodynamic with behavioral factors and focuses on interpersonal and transference issues, failed to find any advantage of CAT over educational behavioral therapy or focal family therapy in eating, mood, or weight outcomes.^226,^ ^228^ Focal family therapy focused on eliminating the eating disorder from its controlling role in determining the relationship between the patient and other family members.

Family therapy. Of the three studies in this category, Dare et al. found family therapy to be superior to routine treatment but equivalent to a focal time-limited psychodynamic psychotherapy in increasing percentage of adult body weight, restoring menstruation, and decreasing bulimic symptoms; overall clinical improvement was modest, however.^228^

Crisp et al.^227^ found outpatient individual and family therapy with variable numbers of sessions to be superior to referral to a family physician for increased weight at 1- and 2-year followup.

The efficacy of family therapy in treating adults with AN has not yet been completely addressed. It may be more effective than medical management by a family physician and routine treatment; family therapy (including the family of origin) may be more effective in younger patients with shorter duration of illness. No studies have explored family therapy for adult patients that included the family of insertion (spouse and offspring of the patient) rather than the family of origin.

Behavioral interventions for adolescents with anorexia nervosa. We present behavioral interventions for adolescents with AN in Table 10.

Family therapy. Four family therapy studies focused exclusively on adolescents and one combined adolescent and adult patients.^231^ Family therapy was more effective for younger patients with earlier onset than for older patients with a more chronic course in the United Kingdom trial performed by Russell et al.^231^ and the followup by Eisler et al.^239^ These studies did not yield evidence that the specific type of family therapy administered was helpful for the older more chronic group.^228,^ ^231^ A form of family therapy focusing initially on parental control of re-nutrition delivered in two different manners revealed a significant advantage of conjoint therapy (family treated as a unit) over separated family therapy (parents and patient seen separately) on eating and mood outcomes but not on weight outcomes.^221^

In a second study, no differences emerged between family therapy and family psychoeducation on any outcomes at 16 weeks.^229^ For a specific form of family therapy, when delivered in conjunction with a common medical and dietary regimen, behavioral family systems therapy (BFST), also characterized initially by parents taking control of renutrition, Robin et al. found BFST to be superior to ego-oriented individual therapy in increasing BMI and restoring menstruation, although neither therapy was superior on eating or mood outcomes.^230,^ ^237^ Addressing the issue of optimal duration of family therapy, Lock et al. randomized adolescents to either short (10 sessions over 6 months) or long (20 sessions over 12 months) manualized family therapy based on the initial parental control of refeeding model^242^ and found no differences on eating, psychiatric, or biomarker outcomes.^222^ Longer-term family therapy suggested that those with more severe eating-related obsessions and nonintact families did better with longer treatment. Finally, in the one study that included both adolescents and adults, family therapy was superior to individual therapy for adolescent patients with shorter duration of illness. This difference did not emerge for adult patients with longer duration of illness.^231^ Although few differences were observed across interventions, specific forms of family interventions did consistently show improvement over time with adolescent patients.

Summary of behavioral interventions for adults and adolescents with anorexia nervosa. Overall, one study of adults provides tentative evidence that CBT may reduce relapse risk for adults with AN after weight restoration has been accomplished.^223^ Sufficient evidence does not exist to determine whether CBT is effective during the acute phase of the illness (i.e., in the underweight state before weight restoration); one study found that a manualized nonspecific supportive treatment (NCSM) was more effective than CBT or IPT in terms of global outcome during the acute phase.^224^ The three family therapy studies provide no support for the efficacy of the type of family therapy delivered in adults with AN with longer duration of illness; the superiority of this approach for younger patients with a shorter illness course is based on one study.^231^ Two studies failed to find any benefit of CAT for eating, mood, or weight outcomes when compared to other treatments for this population.^226,^ ^228^ No methodologically sound studies that systematically tested combinations of medication and psychotherapy were identified.

Serious methodological concerns arose with some of these trials. Two were very small (8 to 12 participants per group),^225,^ ^230^ which does not provide adequate statistical power for the comparative analyses conducted. In addition, both had marked pretreatment differences between groups. Failure to control for contact time with a clinician while comparing multiple treatments, with some groups getting up to 80 percent more time in treatment than others, was another problem.^228^ In addition, only one group of researchers conducted a follow-up study to determine the long-term impact of their interventions.^239^

Five studies evaluated family therapy in adolescents with AN. Overall, family therapy based on principles of parental control of initial refeeding leads to clinically meaningful weight gain and psychological change. However, the majority of family therapy studies compares one form of family therapy to another form and were underpowered to detect significant differences between active similar treatments. One study suggested that family therapy was superior to a non-family therapy comparison intervention for adolescent patients with relatively short duration of illness.^231^ One additional study reported significantly greater weight gain at the end of treatment in family therapy than in ego-oriented individual therapy for adolescent AN patients.^230^ The other three studies all involved some sort of family treatment - either comparing conjoint to separated family therapy or comparing family therapy to family psychoeducation.^221,^ ^229^ Conjoint therapy was superior to separated family therapy for improving eating and mood but not weight outcomes.^221^ Similarly, one study examining family therapy versus family psychoeducation found no differences between groups.^229^

Inadequate statistical power was a common problem among the behavioral interventions in AN, and power calculations were rarely reported. No studies had a pure no-treatment condition, which is appropriate given the gravity of the illness, although “usual” treatment took various forms. Many of these studies had adequate power to detect pre-post within-group differences or differences between no treatment and an active treatment, but few were adequately powered to detect differences across two or more treatment groups.

## Key Question 2: Harms of Treatment for Anorexia Nervosa

Table 11 presents adverse events associated with treatments for AN reported in each of the 32 studies reviewed. Assuming that all relevant adverse events were reported, the most common was the need for inpatient treatment among participants in an outpatient trial. Eight studies reported that one or more participants dropped out because of the need for inpatient treatment. In one study, a participant died before commencing the intervention. In these cases, the events observed may be more ongoing features of the course of illness than an adverse event caused by the intervention per se. In behavioral interventions, physical and psychological harms of interventions are rarely reported.

Table 11 Adverse events reported: anorexia nervosa

Intervention | Adverse Events Reported*
Medication Trials
Fluoxetine vs. placebo^206^ | Fluoxetine group: insomnia and agitation; blurred vision
Fluoxetine vs. placebo^207^ | No adverse events observed
Amitriptyline vs. cyproheptadine vs. placebo^208^ | Amitriptyline: drowsiness, excitement, confusion, increased motor activity, tachycardia, dry mouth, constipation.
| Cyproheptadine: no consistent pattern observed
| Placebo: drowsiness, excitement, increased motor activity.
Amitriptyline vs. placebo^209^ | Amitriptyline group: diaphoresis (2), drowsiness (6), dry mouth (4), blurred vision (1), urinary retention (1), hypotension (2), leucopenia (1)
| Placebo: dry mouth (2), palpitations (1), dizziness (2)
Estrogen vs. nonmedication control^210^ | Estrogen group: depression (1), hyperlipidemia (1)
Growth hormone vs. placebo^212^ | No adverse events observed
Testosterone vs. placebo^211^ | Testosterone group: Mild skin irritation at patch site (3), increased depression (1), increased fatigue and vertigo (1), nausea (1)
| Placebo: Mild skin irritation at patch site (1)
Zinc vs. placebo^213^ | NR
Behavioral Interventions Trials
Behavioral family systems vs. ego-oriented individual^230,237^ | NR
CBT vs. behavioral therapy vs. control^225^ | NR
CBT vs. interpersonal psychotherapy vs. nonspecific supportive clinical management^224^ | No adverse events observed
CBT vs. nutritional counseling^223^ | CBT: Depression and suicidal ideation (1)
| Nutritional: Depression and suicidal ideation (3)
Cognitive analytical vs. educational behavioral^226^ | NR
Conjoint family vs. separated family^221^ | NR
Family therapy vs. family group psychoeducation^229^ | NR
Family therapy vs. nonspecific individual^231,239^ | NR
Focal psychotherapy vs. family therapy vs. cognitive analytical vs. routine treatment^228^ | NR
Inpatient + 12 individual/family vs. outpatient individual/family variable vs. 10 outpatient group vs. family physician vs. dietary counseling^227,238^ | NR
Short- vs. long-term family therapy^222^ | NR: Dropout attributed to other psychological problems

CBT, cognitive behavioral therapy; NR, not reported; vs., versus.

* If no numbers appear in parentheses, authors had only listed adverse events but not reported the number of cases.

For the trials using second-generation antidepressants, we refer to recent publications on the comparative effectiveness and tolerability of second-generation antidepressants.^243^ Common side effects associated with the use of second-generation antidepressants in major depressive disorder are nausea, headache, diarrhea, constipation, dizziness, fatigue, sweating, and sexual side effects. Rare but severe adverse events include hyponatremia, suicidality, and seizures. Up to 90 percent of patients experienced at least one adverse event during treatment. Overall, discontinuation rates attributed to adverse events did not differ significantly among individual drugs and ranged from 6 percent to 14 percent. The authors report no substantial differences in adverse events with respect to drugs that were also used in eating disorders trials (i.e., citalopram, fluoxetine, fluvoxamine, and sertraline).

Given the small sample sizes and completion rates of the two fluoxetine trials, we cannot draw definitive conclusions regarding whether harms associated with fluoxetine treatment in the underweight state differ in any way from treatment of normal-weight individuals with other psychiatric diagnoses. In these studies, Kaye et al. failed to report adverse events;^207^ Attia et al. reported one case of insomnia and agitation and one case of blurred vision.^206^

For tricyclic antidepressants, Halmi et al. reported sporadic cases of drowsiness, excitement, confusion, increased motor activity, tachycardia, dry mouth, and constipation associated with amitriptyline;^208^ however, the rate of adverse events did not differ from placebo.

The only specific adverse event associated with testosterone administration was skin irritation at the patch site. Estrogen administration yielded one case of depression and one of hyperlipidemia. No adverse effects were reported with either growth hormone or zinc administration.

## Key Question 3: Factors Associated With Treatment Efficacy

We found no consistent factors associated with better or poorer treatment outcome across studies. In medication studies, individuals with the nonbulimic subtype of AN had better therapeutic outcomes on cyprohoptadine than amitriptyline and placebo.^208^ Bone density increased more in women with AN who were less than 70 percent of ideal body weight on estrogen replacement therapy.^210^ These subgroup analyses had very small samples, and conclusions should be regarded as tentative.

One observation that was an artifact of experimental design,^223^ post-weight restoration trial of CBT and nutritional counseling is related to patients being permitted to be on antidepressant medication. In one trial, a significantly higher percentage of CBT successes occurred among patients on medication. Miller et al.^211^ reported that 3 weeks of transdermal testosterone was superior in decreasing depression in individuals who were depressed at baseline.

In terms of family therapy, Lock et al. found that adolescents with severe eating-related obsessive-compulsive-related thinking and those who come from nonintact families benefitted from longer-term rather than shorter-term manual-based family therapy treatment.^222^ Eisler et al. found that families that scored higher on maternal criticism did better in separated rather than conjoint family therapy.^221^

Finally, with reference to weight gain, family therapy was more effective for AN patients whose illness began at an early age and had not become chronic.^231,^ ^239^

## Key Question 4: Treatment Efficacy by Subgroups

The total number of individuals enrolled in the eight medication trials that reported the sex of the participants was 320. Of those, one was male. No medication studies reported differential outcome by age. With the exception of the one rGH trial^212^ and one amitriptyline trial,^209^ no medication studies have explicitly focused on the treatment of adolescent AN. Not a single medication study reported race or ethnicity of participants. Of the eight trials, seven were conducted in the United States and one in Canada. Based on these results, we conclude that no information exists regarding differential efficacy of pharmacotherapy interventions for AN by sex, gender, age, race, ethnicity, or cultural group.

The total number of individuals enrolled in the 11 psychotherapy trials was 572; of these, 22 were men or boys. Only two trials reported race or ethnicity of participants; they included eight Asian Americans, 10 Hispanic Americans, no African Americans, and three individuals of “other” race or ethnicity. In no instance were results analyzed specifically by race or ethnic group. No data exist regarding differential efficacy of psychotherapeutic treatment for AN by sex, gender, race, ethnicity, or cultural group.

In terms of age, scant evidence shows that interventions involving the family have greater efficacy for individuals below the age of 15 than for patients above that age. This information is based solely on studies by just one team of investigators who found family therapy to be more effective for adolescent AN patients with a shorter duration of illness than for adults with a more chronic course.^231,^ ^239^ However, no definitive replications have been done. Moreover, no studies have explored the role of family therapy in adults focusing on the family of insertion rather than family of origin, which may be the relevant comparison, or other adaptation of family therapy for adults or adolescents.