# Methods

In this chapter, we document the procedures that the RTI International - University of North Carolina at Chapel Hill Evidence-based Practice Center (RTI-UNC EPC) used to develop this comprehensive evidence report on the management and outcomes related to eating disorders. To provide a framework for the review, we first present the key questions and their underlying analytic framework. We then describe our strategy for identifying articles relevant to our key questions, our inclusion/exclusion criteria, and the process we used to abstract relevant information from eligible articles and generate our evidence tables. We also discuss our criteria for grading the quality of individual articles and the strength of the evidence as a whole. Last, we explain the peer review process.

## Key Questions and Analytic Framework

This report spans key questions (KQs) regarding both treatment and outcomes of three eating disorders: anorexia nervosa (AN), bulimia nervosa (BN), and eating disorders not otherwise specified (EDNOS), which we refined to focus exclusively on binge eating disorder (BED) because of the lack of availability of data on other EDNOS conditions. We examine issues concerning treatment efficacy and disease outcomes separately for each disorder. The American Psychiatric Association and Laureate Psychiatric Clinic and Hospital initially offered these questions, and we put them into final form with input from our Technical Expert Panel (TEP).

### Key Questions

- 1. What is the evidence for the efficacy of treatments or combination of treatments for each of the following eating disorders: AN, BN, and BED?
- 2. What is the evidence of harms associated with the treatment or combination of treatments for each of the following eating disorders: AN, BN, and BED?
- 3. What factors are associated with the efficacy of treatment among patients with the following eating disorders: AN, BN, and BED?
- 4. Does the efficacy of treatment for AN, BN, and BED differ by sex, gender, age, race, ethnicity, or cultural group?
- 5. What factors are associated with outcomes among individuals with the following eating disorders: AN, BN, and BED?
- 6. Do outcomes for AN, BN, and BED differ by sex, gender, age, race, ethnicity, or cultural group?

In the analytic framework for these questions (Figure 1), we depict the partially overlapping syndromes of AN, BN and BED, the two types of studies included in this review (treatment and outcome analyses), and factors that influence both treatment response and disorder outcome. We do not include in our figure influencing factors, such as physical and sexual abuse, that are not discussed in the literature meeting our inclusion criteria.

Figure 1. Analytic framework

Also depicted on the framework are the six KQs discussed in this report. KQ 1 addresses the efficacy of available treatments for the three disorders; we categorize outcomes as eating-related outcomes that deal with the core behavioral and psychological pathology of the disorders, psychiatric or psychological outcomes that focus on the presence of comorbid depression and anxiety, and biomarker outcomes that reflect weight, body mass index (BMI), and other biological indices of the disorders. Treatment may include relapse, diagnostic crossover, and symptomatic change. KQ 2 explores the harms associated with both medication and psychological treatments for these disorders. KQs 3 and 4 highlight the roles of illness-related factors (e.g., comorbid depression, subtype of the eating disorders, early onset of illness) and illness-independent factors (e.g., sex, gender, race or ethnicity, age) in influencing the outcomes of treating these conditions.

KQ 5 addresses short- and long-term outcomes of the disorders. We apply information from observational, cohort, and case series investigations and focus on eating-related, psychiatric or psychological, and biological indices. Finally, KQ 6 highlights whether these outcomes differ by sex, gender, age, race or ethnicity, or cultural groups.

## Literature Review Methods

### Inclusion and Exclusion Criteria

After discussions with our TEP, we generated a list of article inclusion and exclusion criteria (Table 4) for these KQs. We limited our review to human studies, including participants ages 10 years and older. Although interest is growing in developing appropriate nomenclature and interventions for young children with eating disorders,^120^ we judged this literature to be beyond the scope of this review. We considered studies published in all languages from 1980 to September 2005. We included studies conducted with participants of both sexes, in all nations. The study population must be primarily diagnosed with AN, BN or BED.

Table 4 Eating disorders literature searches: inclusion and exclusion criteria

Category | Criteria
Study population | Humans
| All races, ethnicities, and cultural groups
| 10 years of age or older.
Study settings and geography | All nations
Time period | Published from 1980 to the present
Publication criteria | All languages
| Articles in print
| Articles in the “gray literature,” published in nonpeer-reviewed journals, or unobtainable during the review period were excluded.
Admissible evidence (study design and other criteria) | Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results.
| Anorexia nervosa must be diagnosed according to DSM III, DSM III-R, DSM IV, ICD-10, Feighner, or Russell criteria.
| Bulimia nervosa must be diagnosed according to DSM III-R, DSM IV, or ICD-10 criteria.
| Eating disorders not otherwise specified (binge eating disorder) must be diagnosed according to DSM IV criteria.
| Relevant outcomes: eating related, psychiatric or psychological, and biomarker measures; must be able to be abstracted from data presented in the papers.
| Eligible study designs include:
| Randomized controlled trials (RCTs):
| Double-blinded, single-blinded, and cross-over designs (data from prior to the first cross-over).
| Anorexia nervosa studies: initiated with 10 or more participants and followed for any length of time.
| Eating disorders not otherwise specified (binge eating disorder) studies: initiated with 10 or more participants and followed for any length of time.
| Bulimia nervosa studies: initiated with 30 or more patients and followed for a minimum of 3 months.
| Outcomes studies:
| Observational studies including prospective and retrospective cohort studies and case series studies, with and without comparison populations.
| Disease population must be followed for a minimum of 1 year. Disease population must include 50 or more participants at the time of the analysis.

We excluded data that combined diseases because such mixed information would preclude us from separately examining evidence on any one of the three conditions. We also excluded editorials, letters, and commentaries; articles that did not report outcomes related to our key questions; and studies that did not provide sufficient information to be abstracted. Studies were required to report on at least one of our outcomes categories of interest: eating, psychiatric and psychological, or biomarker measures.

We defined individuals as having one of the three disorders of interest according to specific diagnostic criteria. We examined the impact of treatment through a review of the RCT efficacy of treatment literature.

To address a TEP concern that the size of the available AN and BED literature was too limited to permit us to constrain this review based on sample size or followup duration, we included very small AN and BED RCT treatment studies in our review (10 or more participants) and did not require specified followup durations for a study to be included. The BN literature, however, is much more voluminous, which allowed us to limit the treatment studies to larger ones (i.e., those with 30 or more participants).

To help ensure that we were not measuring short-term fluctuations in disease symptoms, we required BN efficacy of treatment studies to follow patients for a minimum of 3 months. The decision to place more stringent requirements on the BN literature was made in consultation with our TEP. Because of financial and time considerations, we used a recently completed EPC report entitled Drug Class Review on Second Generation Antidepressants ^121^ as a starting point for our discussion of harms or side effects related to receiving treatment for AN, BN, and BED; we then supplemented this information with harms reported in the RCT studies meeting our inclusion criteria.

We examined outcomes related to having one of the three eating disorders through a review of observational studies; outcomes included eating, psychiatric or psychological, and biomarker variables and death. Although many participants followed in these studies have received treatment, the outcomes of interest relate not to efficacy of treatments but rather to disease levels and other problems that persist over time. To avoid reporting short-term fluctuations among the disease populations and to have sufficient sample sizes to observe changes over time, we limited our review to studies of 50 or more individuals, followed for a minimum of 1year, with or without comparison groups. Our TEP concurred with this plan.

For both the RCT and outcome literatures, we were unable to perform pooled meta-analyses. Given the absence of consensus definitions of remission, recovery, and relapse for eating disorders, as well as the overabundance of outcome measures, we judged meta-analysis to be both inadvisable and infeasible.

### Literature Search and Retrieval Process

Databases and search terms. To identify the relevant literature for our review, we conducted systematic searches based on search terms, reviewed included studies by our TEP, and hand searched reference lists. We searched standard electronic databases such as MEDLINE®, the Cumulative Index to Nursing and Applied Health (CINAHL), PsycINFO, the Educational Resources Information Center (ERIC), the National AGRICultural OnLine Access (AGRICOLA), and Cochrane Collaboration libraries.

Based on inclusion/exclusion criteria specified above, we generated a list of Medical Subject Heading (MeSH) search terms, supplemented by key word searches of MEDLINE®. Comparable terms were used to search other databases. MeSH terms included anorexia, anorexia nervosa, and bulimia. Text terms included binge eating disorder. We limited our searches by type of study, including RCT, single-blind method, double-blind method, random allocation, longitudinal studies, and observational studies. For interventions, we used therapeutics or cognitive therapy or family therapy or drug therapy or therapy, computer-assisted. For outcomes of disease, we used outcome assessment (health care), treatment outcome, outcome and process assessment (health care), and recurrence. Finally, we asked our external peer reviewers for titles of articles that we may have missed.

Figure 2 presents the yield and results from our searches. We conducted our initial search in late 2004 and updated it in August 2005 (treatment studies) and September 2005 (outcome studies). Beginning with a yield of 2,188 titles and abstracts, we reviewed and further narrowed this pool to 478 articles.

Figure 2. Eating disorders article disposition

We retained the following for our review to answer KQs about treatment efficacy: 35 articles on AN, 58 articles on BN, and 26 articles on BED. To answer KQs about disease outcomes, we retained 38 articles on AN, 14 articles on BN, 7 articles on both AN and BN, and 3 articles on BED.

Article selection process. Once we had identified articles through the electronic database search, review articles, and bibliographies, we examined titles and abstracts to determine whether the studies met our inclusion criteria. One reviewer initially evaluated abstracts for inclusion or exclusion. If one reviewer concluded that the article should be included, it was retained. Abstracts initially excluded from the study by one reviewer received a second review by senior project staff—Nancy Berkman, PhD, MLIR (Project Director), Cynthia Bulik, PhD (Scientific Director), or Gerald Gartlehner, MD, MPH (UNC Project Manager).

In all, 478 articles appeared to meet our inclusion criteria through abstract review, so we obtained the full articles. For the full article review, one senior reviewer read each article and determined if it met our eligibility criteria. Those articles that the reviewer determined did not meet our criteria were re-reviewed by a second senior reviewer to ensure agreement that the article should be excluded. We assigned each of these articles one or more reasons for exclusion.

## Literature Synthesis

### Development of Evidence Tables and Data Abstraction Process

The senior staff members for this systematic review jointly developed the evidence tables. We created two designs for the evidence tables, one for KQs 1 to 4 (treatment studies) and one for KQs 5 and 6 (outcome studies). They are intended to provide sufficient information for readers to understand the study and determine its quality; we emphasized presenting information essential to answering the main questions. The formats of the two sets of evidence tables were based on successful designs used for prior systematic reviews.

Columns in the evidence tables for treatment studies report baseline and outcome measures for eating-related, psychological or psychiatric, and biomarker variables. For each outcome measured, the tables present data in a consistent format. Given the large number of outcomes that these studies typically report, our evidence table entries are relatively long. In contrast, the outcome studies evidence tables are shorter. However, because of the appreciable variety of study approaches and outcomes reported in this literature the presentation of outcome data is, by necessity, less consistent than that for the treatment studies.

For this work, the RTI-UNC EPC team decided to abstract data from included articles directly into evidence tables; this system has worked effectively in many of our past reviews. Because we bypassed the use of data abstraction forms, we had significant efficiencies in production.

We trained data abstractors intensively, thoroughly familiarizing them with table designs, required information and formats, and examples of abstracted articles. As the work progressed, we shared various reporting requirements with abstractors to ensure that information appeared in a consistent and easily understandable manner.

For both the treatment and the outcomes literatures, the first reviewer (UNC faculty, postdoctoral psychology fellow, or psychology graduate student) initially entered data from the article into the evidence table. The second reviewer (Drs. Berkman, Bulik, Brownley, Carey, or Gartlehner) read the article and edited the initial table entry for accuracy, completeness, and consistency. All disagreements concerning the information reported in the evidence tables were reconciled by the two abstractors.

The final evidence tables are presented in their entirety in Appendix C *. Separate tables are included for treatment studies by disease and type of treatment intervention:

* Appendixes cited in this report are provided electronically athttp://www.ahrq.gov/downloads/pub/evidence/pdf/eatingdisorders/eatdis.pdf.

- AN: Evidence Table 1, medication trials; Evidence Table 2, medication plus behavioral intervention trials; Evidence Table 3, behavioral intervention trials (adults); and Evidence Table 4, behavioral intervention trials (adolescents ages 10 and older);
- BN: Evidence Table 5, medication trials; Evidence Table 6, medication plus behavioral intervention trials; Evidence Table 7, behavior intervention with no medications trials; Evidence Table 8, self-help interventions trials; and Evidence Table 9, other interventions trials;
- BED: Evidence Table 10, medication trials; Evidence Table 11, medication plus behavioral interventions trials; Evidence Table 12, behavioral intervention with no medications trials; Evidence Table 13, self-help intervention trials; and Evidence Table 14, other interventions trials.

Appendix C also presents three evidence tables for outcome studies organized only by disease:

- AN outcome studies, Evidence Table 15;
- BN outcome studies, Evidence Table 16; and
- BED outcome studies, Evidence Table 17.

Within each evidence table, entries are listed alphabetically by the last name of the first author. Abbreviations and acronyms used in the tables appear in a glossary at the beginning of the appendix.

Finally, as noted earlier, the number of assessment instruments that investigators used for both diagnosis and outcome measurement in the studies reviewed here was extremely large. To help readers identify these, we created Table 5 (found at the end of this chapter) to briefly identify all measures, their acronyms or abbreviations, and their subscales, with a citation to a definitive source for the instrument.

Table 5 Diagnostic and outcome measures used in randomized controlled trials and outcome studies

Acronym and Full Name of Test | Description of Test and Subscales
ABOS: Anorectic Behaviour Scale for Inpatient Observation^124^ | Proxy-report (relatives) questionnaire to obtain information about patient's behaviors and attitudes; 3 factors: eating behaviors, concerns with weight and food, denial of proteins; bulimic-like behaviors; hyperactivity.
ABS: Anorectic Behavior Scale^125^ | Administrator-completed questionnaire about patient's behavior while in hospital; 8 items on resistance to eating, 8 items on methods of disposing of food, 6 items on overactivity.
ANSS: Anorexia Nervosa Symptom Score^126^ | Clinical rating scale with psychological, social, and physical severity scores and subscales.
BAT: Body Attitudes Test^127,128^ | Self-report questionnaire to measure subjective body experience and attitude towards one's body; 3 factors: negative attitudes about body size, lack of familiarity with one's own body, body dissatisfaction.
BDI: Beck Depression Inventory^129^ | One of the most widely used self-report measures for depression. It is a 21-item test presented in multiple choice format that measures the presence and degree of depression in adolescents and adults.
BEDCI: Binge Eating Disorder Clinical Interview^130^ | Structured clinical interview to establish the diagnosis of BED and both purging and nonpurging types of BN.
BES: Binge Eating Scale^131^ | Self-report measure of binge eating severity as measured by loss of control over eating behavior; 8 items on behavioral manifestations, 8 items on feelings and cognitions.
BIAQ: Body Image Avoidance Questionnaire^132^ | Self-report measure to assess avoidance of situations that provoke concern about physical appearance (including wearing tight fitting clothing, social outings, physical intimacy); 4 subscales: Eating Restraint, Clothing, Grooming/Weighing, Social Activities
BITE: Bulimic Investigation Test Edinburgh^133^ | Brief self-report questionnaire with 2 subscales designed to assess the symptoms and severity of binge eating episodes.
BSI: Brief Symptom Inventory^134^ | Brief self-report instrument to assess patients at intake for psychiatric problems; 9 Primary Symptom Dimensions: Somatization, Obsessive-Compulsive, Interpersonal Sensitivity, Depression, Anxiety, Hostility, Phobic Anxiety, Paranoid Ideation, Psychoticism; 3 Global Indices: Global Severity Index, Positive Symptom Distress Index, Positive Symptom Total.
BSQ: Body Shape Questionnaire^135^ | Self-report inventory to measure worries about weight and body shape.
BSQ-short version: Body Shape Questionnaire - Short Version^136^ | Self-report inventory to measure worries about weight and body shape.
BSS: Body Satisfaction Scale^137^ | Self-report instrument to assess body image satisfaction; 3 subscales: general, body, head.
Bulimic Thoughts Questionnaire^138^ | Self-report instrument of cognitive patterns and distortions associated with bulimic behavior.
CBCL: Child Behavior Checklist^139^ | Parent-report standardized assessment of behavioral problems and social competencies of children ages 4 to 18; 3 scores: total, internalizing behaviors (fearful, shy, anxious, inhibited), externalizing behaviors (aggressive, antisocial, under controlled).
CCEI: Crown-Crisp Experimental Index^140^ | Scale to measure neurotic symptomatology; 6 subscales: free-floating anxiety, phobic anxiety, obsessionality, somatic concomitants of anxiety, depression, hysterical personality.
CDI: Children's Depression Inventory^141^ | Brief self-report test to measure cognitive, affective, and behavioral signs of depression in persons 6 to 17 years of age; 5 factors: negative mood, interpersonal problems, ineffectiveness, anhedonia, negative self-esteem.
CDRS: Contour Drawing Rating Scale^142^ | Instrument to assess body size perception and dissatisfaction; 9 male and 9 female contour drawings shown to subjects who are asked to indicate which most closely resembles their current size and their ideal figure; the discrepancy is a measure of body dissatisfaction in 3 scores: real body, ideal body, body satisfaction index.
CGI or GIS: Clinical Global Impression^143^ | Clinician-rated scale to assess treatment response in psychiatric patients; 3 subscales: severity of illness (CGI-S), global improvement (CSI-G), efficacy index (CGI-EI).
DICA-R: Diagnostic Interview for Children and Adolescents - Revised^144^ | Semistructured clinical interview to determine Axis I psychiatric diagnoses in children and adolescents.
DIET: Dieter's Inventory of Eating Temptations^145^ | Self-report inventory to assess behavioral competence in 6 weight control situations: overeating, negative emotions, exercise, resisting temptation, positive social, food choice.
DSED: Diagnostic Survey for Eating Disorders^146^ | Self-report questionnaire to quantify frequency of disturbed behavior.
EAT: Eating Attitudes Test^147^ | Standardized self-report measure of symptoms and concern characteristics of eating disorders; 2 versions: EAT-26, EAT-40.
EDE: Eating Disorder Examination^148^ | Semistructured interview to measure specific psychopathology of anorexia nervosa and bulimia nervosa; 4 subscales: dietary restraint, eating concern, weight concern, shape concern.
EDE-Q4: Eating Disorders Evaluation Questionnaire - Version 4^149^ | Self-report assessment of thoughts and behaviors commonly found in eating disorders; 4 subscales: dietary restraint, eating concern, weight concern, shape concern.
EDI-1: Eating Disorder Inventory-1^149^ | Self-report questionnaire to measure psychiatric and behavioral traits commonly associated with eating disorders; 8 scales: drive for thinness, bulimia, body dissatisfaction, ineffectiveness, perfectionism, interpersonal distrust, interoceptive awareness, maturity fears.
EDI-2: Eating Disorder Inventory-2^150^ | Standardized self-report measure of psychiatric symptoms commonly associated with anorexia nervosa, bulimia nervosa, or other eating disorders; 8 subscales as for EDI-1, plus asceticism, impulse regulation, and social insecurity.
FACES III: Family Adaptability and Cohesion Evaluation Scales^151^ | Instrument to assess family adaptation and cohesion. Family cohesion assesses degree of separation or connection of family members to the family; 4 levels of family cohesion range from extreme low cohesion to extreme high cohesion: disengaged, separated, connected, enmeshed; 4 levels of adaptability: rigid, structured, flexible, chaotic.
FAM III: Family Assessment Measure^152^ | Self-report measure that assesses the strengths and weaknesses of functioning within a family; can be completed by pre-adolescents, adolescents, and adult family members (ages 10 years to adult); contains 7 subscales: Task Accomplishment, Role Performance, Communication, Affective Expression, Involvement, Control, Values and Norms.
FES: Family Environment Scale^153^ | Instrument to assess actual, preferred, and expected social environment of all types of families; 10 subscales: cohesion, expressiveness, conflict, independence, achievement, intellectual-cultural, active-recreation, moral-religious, organization, control.
FMPS: Frost Multidimensional Perfectionism Scale^154^ | Self-report measure of perfectionism; original measure had 6 subscales (Concern Over Mistakes, Personal Standards, Parental Expectations, Parental Criticism, Doubts About Actions, Organization).
FNE: Fear of Negative Evaluation^155,156^ | Scale to measure social anxiety about receiving negative evaluations from others; 2 subscales: Negative Expectations, Negative Public Evaluation.
Brief-FNE: Brief Fear of Negative Evaluation^157^ | Brief version of the original FNE.
FRS: Figure Rating Scale^158^ | Silhouette drawings of male and female adult body figures ranging from very thin to very large used as measure of personal body perception; 3 subscales: Real Body, Ideal Body, Body Satisfaction Index.
GAAS: Goldberg Anorectic Attitude Scale^159^ | Scale to measure short-term changes in anorectic cognitions across treatment including measures of hyperactivity, access, self-care, selective appetite, and denial of illness.
GAF: Global Assessment of Functioning^16^ | Clinician-derived instrument to measure the highest level of social and occupational functioning in the previous week and year; sometimes broken down into the GAF-F function score (not including symptoms) and the GAF-S symptom score (not including function).
GIS: Global Improvement Scale^143^ | See CGI (Clinical Global Improvement Scale).
HAM-A: Hamilton Anxiety Rating Scale^160^ | Semistructured interview to assess severity of anxiety symptomatology.
HAM-D or HDRS: Hamilton Depression Rating Scale^161^ | Semistructured interview to assess an array of behavioral, affective, and vegetative symptoms of depression.
HGSHS: Harvard Group Scale of Hypnotic Susceptibility, Form A^162^ | Measure of susceptibility to a wide range of hypnotic experiences, designed for assessing groups of subjects.
HRQ: Helping Relationship Questionnaire^163^ | Patient-rated instrument to measure therapeutic alliance.
HSCL: Hopkins Symptom Checklist^134^ | Self-report screening instrument to identify common psychiatric symptoms; 9 subscales: somatization, obsessive-compulsive symptoms, interpersonal sensitivity, depression, anxiety, anger or hostility, phobic anxiety, paranoid ideation, psychotic symptoms.
IBC: Interactive Behavior Code^164^ | A global interferential measure of communication, problem solving, and conflict, with 22 coded items rated by independent observers; summary scores are computed for negative and positive communication.
IIP: Inventory of Interpersonal Problems^165^ | Instrument to measure interpersonal problems and level of distress arising from interpersonal sources.
LCB: Locus of Control of Behavior^166^ | Instrument to measure the extent to which individuals believe they are responsible for personal problem behavior.
LIFE: Longitudinal Interval Continuation Evaluation^167^ | Semistructured interview and rating system to assess longitudinal course of psychiatric disorders in several areas: psychopathology, nonpsychiatric mental illness, treatment, psychosocial functioning, overall severity, narrative account.
MCMI: Millon Clinical Multiaxial Inventory^168^ | Lengthy test to diagnose 14 personality disorders and 10 clinical syndromes; scales: 14 Personality Pattern Scales, 10 Clinical Syndrome Scales, 3 Modifying Indices, 1 Validity Index.
MMPI: Minnesota Multiphasic Personality Inventory^169^ | Test of adult psychopathology; 8 Validity Scales, 5 Superlative Self-Presentation Subscales, 10 Clinical Scales, 9 Restructured Clinical (RC) Scales, 15 Content Scales, 27 Content Component Scales, 20 Supplementary Scales, 31 Clinical Subscales (Harris-Lingoes and Social Introversion Subscales), and various special or setting-specific indices.
MOCI: Maudsley Obsessive Compulsive Index^170^ | Self-report questionnaire to measure the presence of obsessional-compulsive behaviors; scores: total obsessional symptoms; checking; washing; doubting/conscientious; slowness/repetition.
MPS: Multidimensional Perfectionism Scale^154^ | Self-report instrument to assess perfectionism; 6 subscales: concern over mistakes, personal standards, parental expectations, parental criticism, doubts about action, organization.
M-R Scales: Morgan and Russell Scales^171^ | Structured interview to give a brief but thorough assessment of the central clinical features of anorexia nervosa; 5 subscales: eating behavior, menstrual state, mental state, relevant attitudes, socioeconomic state; sixth scale allows a self-progress rating.
M-R-H Scale; Morgan-Russell-Hayward Scale^172^ | Guided interview concerned with clinical features of anorexia nervosa to evaluate eating behavior, body weight, mental state, and other attitudes relevant to anorexia nervosa; 5 scales: nutrition, menses, mental state, psycho-sexual state, socioeconomic state; additional subscales include: food intake, concern at body image, body weight, menstrual pattern, disturbance of mental state, attitudes toward sexual matters, overt sexual behavior, attitude to menstruation, relationship with family, emancipation from family, personal contacts, social activities, employment record.
MRT: Vandenberg and Kuse's Adaptation of Shepard and Metzler's Three-dimensional Mental Rotations Test^173^ | Self-report test of visuospatial ability in which participants view a depiction of a 3-dimensional target figure and 4 test figures and determine which of the test figures are rotated versions of the target figure.
PARQ: Parent Adolescent Relationship Questionnaire^174^ | Instrument completed by parents and adolescents 10 through 19 years of age to measure relationship between parents and adolescents; 3 scales: Overt Conflict/Skill Deficits, Extreme Beliefs, Family Structure.
PGWB: Dupuy's Psychological General Well-being Index^175^ | Self-report inventory to measure self-representations of intrapersonal affective or emotional states reflecting a sense of subjective well-being or distress; 6 intrapersonal subscales: anxiety, depressed mood, positive well-being, self-control, general health, vitality.
PSE: Present State Examination^176^ | Global index of mental state disturbance.
PSR: Psychiatric Status Rating^177^ | Clinician-administered instrument to determine the severity of a range of psychiatric disorders that has been used to determine eating disorder outcomes.
QEWP-R: Questionnaire of Eating and Weight Patterns - Revised^178^ | Self-report questionnaire to assess a range of features and problems associated with obesity and eating disorders.
RAS: Rathus Assertiveness Schedule^179^ | Self-report instrument to measure assertiveness.
RSE: Rosenberg Self-Esteem Scale^180^ | Self-report instrument to measure overall self-esteem.
SADS-C: Schedule for Affective Disorders and Schizophrenia-Change Version^181^ | Structured interview to differentiate schizophrenia from mood disorders; 2 subscales: depression, mania.
SAMS (Situational Appetite Measures) Urge and SAMS Efficacy^182^ | Complementary scales to measure the strength of the urge to binge in 40 different situations and the degree of confidence in one's ability to resist a binge in those same 40 situations.
SAS: Social Adjustment Scale^183^ | Self-report questionnaire to assess social and work-related functions; 6 subscales: work, social and leisure, extended family, marital, prenatal, family unit.
SCFI: Standardized Clinical Family Interview^184^ | Standardized clinical interview used with families in which the interviewer tries to get responses from all family members and adopts a neutral style. Questions concern numerous areas of family life, mainly what sort of family it is, who does what, who is like whom, life cycle, roles and responsibilities, conflicts, decisions, discipline, relation to the environment.
SCI: Shapiro Control Inventory^185^ | Self-report measure of the psychological construct of control (comparable to Locus of Control scales) with 9 subscales.
SCID-I: Structured Clinical Interview I for the DSM IV^186^ | Structured diagnostic interview to assess presence of current or past DSM IV Axis I major psychiatric disorders.
SCL-90 R Symptom Checklist 90-Revised^134^ | General measure of psychopathology, including various forms of anxiety, depression, paranoia, psychotic features. Subscales: Global Severity Index (GSI) to measure overall psychological distress; Positive Symptom Distress Index to measure the intensity of symptoms; Positive Symptom Total of number of self-reported symptoms (Somatization, Obsessive-Compulsive, Interpersonal Sensitivity, Depression, Hostility, Phobic Anxiety, Paranoid Ideation, Psychoticism).
SDS: Zung Self-rating Depression Scale^187^ | Self-report assessment to quantify depression, using criteria of pervasive depressed affect and its physiological and psychological concomitants.
SF-36: Medical Outcomes Study Short Form Health Survey^188^ | Self-report questionnaire to assess health-related quality of life; 8 subscales: physical function, role physical, bodily pain, general health, mental health, role emotional, social function, vitality, 2 composite scores: physical health; mental health.
SIAB-P: Structured Interview for Anorexia and Bulimia Nervosa^189^ | Interview to assess severity of current eating disorder symptoms; 6 subscales: body image and ideal of slimness, social integration and sexuality, depression, obsessive compulsive syndromes and anxiety, bulimic symptoms, laxative abuse.
SMFQ: Short Mood and Feeling Questionnaire^190^ | Self-report measure of childhood and adolescent depression for children 8 to 16 years of age.
SOC: Stages of Change Scale^191^ | Self-report inventory to describe how respondents feel as they initiate counseling; 4 subscales: Precontemplation, Contemplation, Action, Maintenance.
SPAQ: Seasonal Patterns Assessment Questionnaire^192^ | Self-report instrument to rate the presence and severity of seasonal variation in mood, sleep, and eating-related variables; 2 added items monitor seasonal bingeing and purging patterns.
STAI: State Trait Anxiety Inventory^193^ | Standardized self-report assessment of both state and trait anxiety (2 subscales).
STAXI: State Trait Anger Expression Inventory^194^ | Self-report inventory to assess components of anger and anger expression of normal and abnormal personality.
STPI: State Trait Personality Inventory^193^ | Self-report personality inventory.
SUDS: Subjective Units of Distress^195^ | Self-report measure of intensity of subjective distress in response to a particular stimulus.
TAS-20: Toronto Alexithymia Scale^196^ | Self-report inventory to assess the alexithymia construct (difficulty recognizing, identifying, and communicating emotions; reduced fantasy capacity; and an externally oriented cognitive style); 2 dimensions: identifying feelings (DIF), describing feelings (DDF).
TCI: Temperament and Character Inventory^197^ | Self-report measure of temperament and character; 7 subscales: Novelty Seeking, Harm Avoidance, Reward Dependence, Persistence, Self-Directedness, Cooperativeness, Self-Transcendence.
TFEQ: Three-Factor Eating Questionnaire^198^ | Self-report inventory; 3 subscales: Cognitive-Restraint, Hunger, Disinhibition. Also known as the Eating Inventory.
WAIS: Wechsler Adult Intelligence Scale^199^ | Structured, clinician-administered general test of intelligence for persons 16 years of age and older; 6 Verbal tests: Information, Comprehension, Arithmetic, Digit Span, Similarities, Vocabulary; 5 Performance subtests: Picture Arrangement, Picture Completion, Block Design, Object Assembly, Digit Symbol.
WELSQ: Weight Efficacy Life Style Questionnaire^200^ | Self-report measure of confidence about successfully resisting the desire to eat; 5 situational subscales: Negative Emotions, Availability, Social Pressure, Physical Discomfort, Positive Activities.
WLFL: Work, Leisure and Family Life Questionnaire^201^ | Self-report instrument to measure social adjustment and functioning; 8 scales: work outside the home, housework, social and leisure activities, extended family, marital, parental-older children, parental-baby, family unit.
YBC-EDS and YBOCS-ED: Yale-Brown-Cornell Eating Disorder Scale^202^ | Interview to assess preoccupations and rituals associated with eating disorders: symptom checklist produces 3 dimensions of preoccupations and rituals (severity, motivation, ego syntonicity) and covers 18 general categories of rituals and preoccupations.
Y-BOCS-BE: Yale-Brown Obsessive Compulsive Scale Modified for Binge Eating^203^ | Clinician-rated inventory of obsessive-compulsive problems adapted for use with binge-eating disorder.
Y-BOCS Score: Yale-Brown Obsessive Compulsive Scale^204^ | Clinician-rated scale with separate subtotals for severity of obsessions and compulsions; 2 subscales: obsessions, compulsions.
Youth Self-Report^139,205^ | Self-report inventory on various behavior problems.

### Quality and Strength of Evidence Evaluation

Rating the quality of individual articles. For this systematic review, we developed our approach to assessing the quality of individual articles using domains and elements recommended in the evidence report by West and colleagues, Systems to Rate the Strength of Scientific Evidence.^122^ We developed two quality-rating forms, one for the treatment literature and the other for the outcomes literature. Quality rating forms did not differ by disease. We tested several drafts of these forms, revising them as needed to ensure that they efficiently captured the desired information. The final grading forms can be found in Appendix B.

We assessed the treatment literature through 25 items in 11 categories: (1) research aim/study question, (2) study population, (3) randomization, (4) blinding, (5) interventions, (6) outcomes, (7) statistical analysis, (8) results, (9) discussion, (10) external validity, and (11) funding/sponsorship. We did not exclude any studies with so-called fatal flaws, such as the approach to randomization. Rather, we reduced the study's overall score if a category was flawed or inadequate. Because patients and those administering interventions in the psychological treatment studies could not be blinded, we did not evaluate these items when studies included these interventions. However, we always evaluated whether the outcome assessor was blinded. Studies that were reported in more than one article were given the same quality grade.

We weighted each item equally and calculated a score out of 100 percent. We then collapsed those scores into three categories: poor, 0 percent to 59 percent; fair, 60 percent to 74 percent; and good, 75 percent or better.

For the outcomes literature, we used 17 items in 8 categories: (1) research aim/study question, (2) study population, (3) eating disorder diagnosis method, (4) study design, (5) statistical analysis, (6) results/outcome measurement, (7) external validity, and (8) discussion. As with the RCTs, we weighted each item equally. Rather than calculating a score out of 100 percent, however, we converted ratings for each item into numeric values of 0, 1, or 2, in which 0 = poor, 1 = fair, and 2 = good. Studies without comparison groups were not evaluated by items addressing this aspect of design. However, studies that included comparison groups were scored as “good” on one item, whereas those without were scored as “poor” on that item. We calculated the mean score for all graded items and we concluded that, overall, an article should be graded as poor with a rating < 1, fair with a rating ≥ 1 and < 1.5, and good with a rating of ≥ 1.5.

Each quality grade was the composite (averaged) rating of two independent evaluators. The only items reconciled between the evaluators were those in which one rater provided a score for the item and the other said the item was not applicable. In assessing quality of the treatment studies, we asked the two evaluators to discuss their results if the difference in their total scores was 20 points or greater, but we did not require them to come to agreement.

Rating the strength of the available evidence. We rated the strength of the evidence base for both interventions and disease outcomes separately for the three diseases, using a single scheme for all bodies of evidence. Starting with the West et al. report that compared various schemes for grading bodies of evidence,^122^ we based our evaluation on criteria developed by Greer et al.,^123^ which we deemed most applicable to the study designs in this review. It includes three domains: quality of the research, quantity of studies (including number of studies and adequacy of the sample size), and consistency of findings.

We graded the body of literature applicable to each of the six KQs separately. For the treatment literature, we further divided studies by whether the intervention was pharmaceutical, behavioral, or a combination. Three senior staff defined by consensus four strength-of-evidence categories, as follows:

- I. Strong evidence base. The evidence is from studies of strong design; results are both clinically important and consistent with minor exceptions at most; results are free from serious doubts about generalizability, bias, or flaws in research design. Studies with negative results have sufficiently large samples to have adequate statistical power.
- II. Moderate evidence base. The evidence is from studies of strong design, but some uncertainty remains because of inconsistencies or concern about generalizability, bias, research design flaws, or adequate sample size. Alternatively, the evidence is consistent but derives from studies of weaker design.
- III. Weak evidence base. The evidence is from a limited number of studies of weaker design. Studies with strong design either have not been done or are inconclusive.
- IV. No evidence base. No published literature.

## Peer Review Process

Among the more important activities involved in producing a credible evidence report is conducting an unbiased and broadly based review of the draft report. External reviewers for this report included clinicians, representatives of professional societies and advocacy groups, and potential users of the report, including TEP members (see Appendix D ^†^). We charged peer reviewers with commenting on the content, structure, and format of the evidence report and asked them to complete a peer review checklist. We revised the report, as appropriate, based on their comments.

† Appendixes cited in this report are provided electronically at [underlined: http://www.ahrq.gov/downloads/pub/evidence/pdf/eatingdisorders/eatdis.pdf].