# Introduction

## Scope of the Problem

The eating disorders discussed in this report include anorexia nervosa (AN), bulimia nervosa (BN), and eating disorders not otherwise specified (EDNOS). Although rigorous epidemiologic data specific only to the United States are lacking, the mean prevalence of AN in young females in Western Europe and the United States is 0.3 percent and the mean prevalence of BN is 1.0 percent. Clinically concerning subthreshold conditions are more prevalent.^1^ These eating disorders are associated with substantial morbidity and mortality.^2,^ ^3^ The financial and social impact of these potentially fatal disorders on disability, productivity, and quality of life remains unknown.

## Anorexia Nervosa

### Clinical Characteristics

AN is a serious psychiatric illness marked by an inability to maintain a normal healthy body weight, often dropping well below 85 percent of ideal body weight. Patients who are still growing fail to make expected increases in weight (and often height) and bone density. Despite increasing weight loss, individuals with AN continue to obsess about weight, remain dissatisfied with the perceived size of their bodies, and engage in an array of unhealthy behaviors to perpetuate weight loss (e.g., purging, dieting, excessive exercise, fasting). Individuals with AN place central importance on their shape and weight as a marker of self-worth and self-esteem. Although amenorrhea is a diagnostic criterion, it is of questionable relevance. There do not appear to be meaningful differences between individuals with AN who do and do not menstruate.^4,^ ^5^ Typical personality features of individuals with AN include perfectionism, obsessionality, anxiety, harm avoidance, and low self-esteem.^6^

The most common comorbid psychiatric conditions include major depression^7,^ ^8^ and anxiety disorders.^9,^ ^10^ Anxiety disorders often predate the onset of the eating disorder,^9,^ ^10^ and depression often persists post-recovery.^11^

### Diagnostic Criteria

Table 1 presents the diagnostic criteria that authors of articles reviewed in this report use. They include Russell criteria,^12^ Feighner criteria,^13^ Diagnostic and Statistical Manual for Mental Disorders III, III-R and IV (DSM III, III-R, and IV),^14^–^16^ and the International Classification of Diseases-Versions 9 and 10 (ICD-9 and ICD-10).^17^

Table 1 Diagnostic criteria: anorexia nervosa

Diagnostic Criteria
Russell's Criteria for Anorexia Nervosa | 1 Patient resorts to a variety of devices aimed at achieving weight loss (starvation, vomiting, laxatives, etc.); 2 Evidence of an endocrine disorder, amenorrhea in the female, and loss of sexual potency and interest in the male; 3 Patient manifests the characteristic psychopathology of a morbid fear of becoming fat. This is accompanied by a distorted judgment by the patient of her body size
Feighner's Criteria for Anorexia Nervosa | 1 Onset prior to age 25; 2 Anorexia with accompanying weight loss of at least 25 percent of original body weight; 3 A distorted implacable attitude toward eating food or weight that overrides hunger, admonitions, reassurances, and threats; 4 No known medical illness accounts for the anorexia [nervosa] and weight loss; 5 No other known psychiatric disorder, with particular reference to primary affective disorders, schizophrenia, obsessive, and compulsive and phobic neurosis; 6 At least two of the following manifestations: amenorrhea, lanugo, bradycardia, periods of overactivity, episodes of bulimia, vomiting
DSM III Criteria for Anorexia Nervosa (307.10) | A Intense fear of becoming obese, which does not diminish as weight loss progresses; B Disturbance of body image (e.g., claiming to “feel fat” even when emaciated); C Weight loss of at least 25% of original body weight or, if under 18 years of age, weight loss from original body weight plus projected weight gain expected from growth charts may be combined to make the 25%; D Refusal to maintain body weight over a minimal normal weight for age and height; E No known physical illness that would account for the weight loss
DSM III-R Criteria for Anorexia Nervosa (307.10) | A Refusal to maintain body weight over a minimal normal weight for age and height (e.g., weight loss leading to maintenance of body weight 15% below that expected or failure to make expected weight gain during period of growth, leading to body weight 15% below that expected); B Intense fear of gaining weight or becoming fat, even though underweight; C Disturbance in the way in which one's body weight, size, or shape is experienced (e.g., the person claims to “feel fat” even when emaciated, believes that one area of the body is “too fat” even when obviously underweight); D In females, absence of at least three consecutive menstrual cycles when otherwise expected to occur (primary and secondary amenorrhea). (A woman is considered to have amenorrhea if her periods occur only following hormone, e.g., estrogen, administration.)
DSM IV Criteria for Anorexia Nervosa (307.10) | A Refusal to maintain body weight at or above a minimally normal weight for age and height (e.g., weight loss leading to maintenance of body weight less than 85% of that expected or failure to make expected weight gain during period of growth, leading to body weight less than 85% of that expected).; B Intense fear of gaining weight or becoming fat, even though underweight.; C Disturbance in the way in which one's body weight or shape is experienced, undue influence of body weight or shape on self-evaluation, or denial of the seriousness of the current low body weight.; D In postmenarchal females, amenorrhea i.e., the absence of at least three consecutive cycles. (A woman is considered to have amenorrhea if her periods occur only following hormone, e.g., estrogen administration.)
| Specify type:
| - Restricting Type: During the current episode of anorexia nervosa, the person has not regularly engaged in binge-eating or purging behavior (i.e., self-induced vomiting or the misuse of laxatives, diuretics, or enemas).; - Binge-Eating/Purging Type: During the current episode of anorexia nervosa, the person has regularly engaged in binge-eating or purging behavior (i.e., self-induced vomiting or the misuse of laxatives, diuretics, or enemas).
ICD-9 Criteria for Anorexia Nervosa (307.1) | A disorder in which the main features are persistent active refusal to eat and marked loss of weight
| The level of activity and alertness is characteristically high in relation to the degree of emaciation
| Typically the disorder begins in teenage girls but it may sometimes begin before puberty and rarely occurs in males
| Amenorrhoea is usual and there may be a variety of other changes including slow pulse and respiration and low body temperature and dependent oedema
| Unusual eating habits and attitudes toward food are typical and sometimes starvation follows or alternates with periods of overeating
| The accompanying psychiatric symptoms are diverse
ICD-10 Criteria for Anorexia Nervosa (F50.0) | A There is weight loss or, in children, a lack of weight gain, leading to a body weight at least 15% below the normal or expected weight for age and height; B The weight loss is self-induced by avoidance of “fattening foods”; C There is self-perception of being too fat, with an intrusive dread of fatness, which leads to a self-imposed low weight threshold; D A widespread endocrine disorder involving the hypothalamic-pituitary-gonadal axis is manifested in women as amenorrhoea and in men as a loss of sexual interest and potency. (An apparent exception is the persistence of vaginal bleeds in anorexic women who are on replacement hormonal therapy, most commonly taken as a contraceptive pill); E The disorder does not meet criteria A or B for bulimia nervosa
ICD-10 Criteria for Atypical Anorexia Nervosa (F50.1) | Disorder that fulfills some of the features of anorexia nervosa but in which the overall clinical picture does not justify that diagnosis. For instance, one of the key symptoms, such as amenorrhoea or marked dread of being fat, may be absent in the presence of marked weight loss or weight-reducing behavior. This diagnosis should not be made in the presence of known physical disorders associated with weight loss

DSM, Diagnostic and Statistical Manual; ICD, International Classification of Diseases. For citations, see text.

### Epidemiology

The mean prevalence of AN in young females in Western Europe and the United States is 0.3 percent.^1^ The prevalence of subthreshold AN, defined as one criterion short of threshold, is greater—ranging from 0.37 percent to 1.3 percent.^18,^ ^19^

Although awareness of the disorder has increased, the data on changing incidence are conflicting. Some studies suggest that the incidence is increasing,^20^–^26^ and others report stable rates.^27^–^31^ Epidemiological studies indicate that the peak age of onset is between 15 and 19 years.^32^ Anecdotal reports suggest increasing presentations in prepubertal children^33^ and new onset cases in mid- and late-life.^34,^ ^35^ The gender ratio for AN is approximately 9:1, women to men.^16^

### Etiology

The etiology of AN remains incompletely understood. Although numerous psychological, social, and biological factors have been implicated as potentially causal, few specific risk factors have been consistently replicated in studies of the etiology of the disorder.^36,^ ^37^ Although not disorder-specific, common risk factors across eating disorders include sex, race or ethnicity, childhood eating and gastrointestinal problems, elevated shape and weight concerns, negative self-evaluation, sexual abuse and other adverse events, and general psychiatric comorbidity.^36^ In addition, prematurity, smallness for gestational age, and cephalohematoma have been identified as risk factors for AN.^38^

The preponderance of reports from western cultures fueled early conceptualizations of AN as a culturally determined disorder, but the past decade of biological and genetic research has revealed that AN is familial^39^ and that the observed familial aggregation is attributable primarily to genetic factors.^40^–^42^ Moreover, molecular genetic studies have identified areas of the human genome that may harbor susceptibility loci for AN^43,^ ^44^ and specific genes that may influence risk.^45,^ ^46^

In addition, an array of pharmacologic, genetic, and neuroimaging studies have identified fundamental disturbances in serotonergic function in individuals with AN even after recovery.^47^ Although serotonin has received considerable research attention, given the interrelatedness of neurotransmitter function, other neurotransmitter systems, most notably dopamine, are also implicated in these disorders.^48^ The ultimate understanding of AN etiology will likely include main effects of both biological and environmental factors as well as their interactions and correlations.

### Course of Illness

AN has serious medical and psychological consequences that can persist even after recovery. Features associated with the eating disorder including depression, anxiety, social withdrawal, heightened self-consciousness, fatigue, and multiple medical complications.^7,^ ^49^–^51^ The social toll of AN interferes with normal adolescent development.^52^ Across psychiatric disorders, the highest risks of premature death, from both natural and unnatural causes, are from substance abuse and eating disorders.^53^

A history of AN is associated with greater problems with reproduction,^54^ osteoporosis,^55^–^57^ continued low body mass index (BMI, a commonly used measure of normal weight, overweight, or obesity calculated as weight in kilograms divided by height in meters squared [kg/m^2^]), and major depression.^11^ Chapter 6 reviews eating-related, psychological, and biomarker-measured outcomes of AN in detail.

### Treatment

Given the high morbidity and mortality associated with AN, developing effective treatments for AN is critical. Because of the frequent medical complications and nutritional compromise, clinical practice typically includes a comprehensive medical evaluation and nutritional counseling. Typically, less medically compromised cases of AN are treated on an outpatient basis by psychiatrists, psychologists, and other therapists with primary care providers managing medical care. Professional organizations have developed several English-language treatment guidelines or position papers for the treatment of AN; these include the American Psychiatric Association,^58^ the National Institute for Clinical Excellence,^59^ the Society for Adolescent Medicine,^60^ the American Academy of Pediatrics,^61^ and the Royal Australian and New Zealand College of Psychiatrists.^62^

Psychotherapeutic approaches include individual psychotherapy (cognitive-behavioral, interpersonal, behavioral, and psychodynamic), family therapy (especially for younger patients), and group therapy. The American Psychiatric Association Working Group on Eating Disorders concluded that hospitalization is appropriate for individuals below 75 percent of ideal body weight.^58^ Weight is not the only parameter to be considered in level of care decisions. Other considerations include medical complications, suicide attempt or plan, failure of outpatient or partial hospitalization treatment, psychiatric comorbidity, role impairment, poor psychosocial support, compromised pregnancy, and lack of availability of less intensive treatment options.^58^ Such treatment commonly involves highly specialized multidisciplinary teams including psychologists, psychiatrists, internists or pediatricians, nutritionists, social workers, and nurse specialists.

Striegel-Moore et al. reported the average length of stay to be 26 days using an insurance database of approximately 4 million individuals in the United States;^63^ this is substantially shorter than the lengths of stay in other countries, including New Zealand (72 days)^64^ and Europe, which ranges from 40.6 days (Finland) to 135.8 days (Switzerland).^65^ They found that, per patient, AN treatment costs in the United States were higher than those for obsessive-compulsive disorder and comparable to those for schizophrenia, both of which have prevalences similar to those of AN.^63^

A workshop sponsored by the National Institute of Mental Health (NIMH) examined problems in conducting research on AN treatment.^66^ It highlighted obstacles such as relatively low incidence and prevalence, lack of consensus on best treatments, variable presentation within the patient population based on age and illness factors, high costs of providing treatment, and the complex interaction of medical and psychiatric problems associated with the illness. This report also highlighted the importance of improving and expanding the workforce in the eating disorders research field.

## Bulimia Nervosa

### Clinical Characteristics

BN is characterized by recurrent episodes of binge eating in combination with some form of inappropriate compensatory behavior. Binge eating is the consumption of an abnormally large amount of food coupled with a feeling of being out of control. Compensatory behaviors (aimed at preventing weight gain) include self-induced vomiting; the misuse of laxatives, diuretics, or other agents; fasting; and excessive exercise.

The onset of BN usually occurs in adolescence or early adulthood and is most frequently seen in women who are of normal body weight.^16^ Although the gender ratio is approximately 9:1, women to men, the diagnostic criteria themselves are gender-biased. In contrast to women, men tend to present with a greater reliance on nonpurging forms of compensatory behavior such as excessive exercise.^67,^ ^68^ Considerations of differences in the clinical presentation of BN in men may lead to revised estimates.^67,^ ^69^

Approximately 80 percent of patients with BN are diagnosed with another psychiatric disorder at some time in their life.^70^ Commonly comorbid psychiatric conditions include anxiety disorders, major depression, dysthymia, substance use, and personality disorders.^9,^ ^71^–^77^ Personality features of individuals with BN include some features shared with AN such as high harm avoidance, perfectionism, and low self-esteem. Features more specific to BN include higher novelty seeking, higher impulsivity, lower self-directedness, and lower cooperativeness.^78^–^80^

### Diagnostic Criteria

Table 2 presents DSM III, III-R, and IV and ICD-10 diagnostic criteria for BN. According to DSM IV criteria, a diagnosis of BN requires a minimum of 3 months of binge eating and compensatory behavior occurring twice a week or more. Similar to AN, individuals have to report the undue influence of weight and shape on their self-esteem. In addition, BN is diagnosed secondary to AN (i.e., the illness is diagnosed as BN only if the criteria for AN are not met). Thus, to be diagnosed with BN, individuals should have a BMI greater than 17.5 or the equivalent in children and adolescents. The DSM distinguishes two subtypes of BN based on the individualapos;s compensatory behavior: purging (including vomiting and misuse of laxatives, diuretics, or enemas) and nonpurging (restricted eating and exercise). The ICD-10^17^describes only the compensatory mechanisms of vomiting and use of purgatives for BN, because of societal pathologizing of vomiting and laxative misuse when compared with exercise or restrictive eating. ICD-10 does acknowledge alternate periods of starvation in BN.

Table 2 Diagnostic criteria: bulimia nervosa

Diagnostic Criteria
DSM III Criteria for Bulimia Nervosa (307.51) | A Recurrent episodes of binge eating (rapid consumption of a large amount of food in a discrete period of time, usually less than two hours); B At least three of the following:; (1) consumption of high-caloric, easily ingested food during a binge; (2) inconspicuous eating during a binge; (3) termination of such eating episodes by abdominal pain, sleep, social interruption, or self-induced vomiting; (4) repeated attempts to lose weight by severely restrictive diets, self-induced vomiting, or use of cathartics or diuretics; (5) frequent weight fluctuations greater than 10 pounds due to alternating binges and fasts; C Awareness that the eating pattern is abnormal and fear of not being able to stop eating voluntarily; D Depressed mood and self-deprecating thoughts following eating binges; E The bulimic episodes are not due to anorexia nervosa or any known physical disorder
DSM III-R Criteria for Bulimia Nervosa (307.51) | A Recurrent episodes of binge eating (rapid consumption of a large amount of food in a discrete period of time); B A feeling of lack of control over eating behavior during the eating binges; C The person regularly engages in either self-induced vomiting, use of laxatives or diuretics, strict dieting or fasting, or vigorous exercise in order to prevent weight gain; D A minimum average of two binge eating episodes a week for at least 3 months; E Persistent overconcern with body shape and weight
DSM IV Criteria for Bulimia Nervosa (307.51) | A Recurrent episodes of binge eating. An episode of binge eating is characterized by both of the following:; (1) Eating, in a discrete period of time (e.g., within any 2-hour period), an amount of food that is definitely larger than most people would eat during a similar period of time and under similar circumstances; (2) A sense of lack of control over eating during the episode (e.g., a feeling that one cannot stop eating or control what or how much one is eating); B Recurrent inappropriate compensatory behavior in order to prevent weight gain, such as self-induced vomiting; misuse of laxatives, diuretics, enemas, or other medications; fasting or excessive exercise; C The binge eating and inappropriate compensatory behaviors both occur, on average, at least twice a week for 3 months; D Self-evaluation is unduly influenced by body shape and weight; E The disturbance does not occur exclusively during episodes of anorexia nervosa
| Specify type:
| Purging type: During the current episode of bulimia nervosa, the person has regularly engaged in self-induced vomiting or the misuse of laxatives, diuretics, or enemas
| Nonpurging type: During the current episode of bulimia nervosa, the person has used inappropriate compensatory behaviors, such as fasting or excessive exercise, but has not regularly engaged in self-induced vomiting or the misuse of laxatives, diuretics, or enemas
ICD-10 Criteria for Bulimia Nervosa (F50.2) | A There are recurrent episodes of overeating (at least twice a week over a period of 3 months) in which large amounts of food are consumed in short periods of time; B There is persistent preoccupation with eating, and a strong desire or sense of compulsion to eat (craving); C The patient attempts to counteract the “fattening” effects of food by one or more of the following:; (1) self-induced vomiting; (2) self-induced purging; (3) alternating periods of starvation; (4) use of drugs such as appetite suppressants, thyroid preparations, or diuretics; when bulimia occurs in diabetic patients they may choose to neglect their insulin treatment; D There is self-perception of being too fat, with an intrusive dread of fatness (usually leading to underweight)
ICD-10 Criteria for Atypical Bulimia Nervosa (F50.3) | Disorder that fulfills some of the features of bulimia nervosa, but in which the overall clinical picture does not justify that diagnosis. For instance, there may be recurrent bouts of overeating or overuse of purgatives without significant weight change, or the typical overconcern about body shape and weight may be absent

DSM, Diagnostic and Statistical Manual; ICD, International Classification of Diseases. For citations, see text.

### Epidemiology

A recent review estimated the prevalence of BN to be 1 percent for women and 0.1 percent for men across Western Europe and the United States.^1^ The prevalence of subthreshold BN was considerably higher: 1.5 percent for full syndrome and 5.4 percent for partial syndrome. Because of the late introduction of BN into psychiatric nomenclature, few studies have explored temporal changes in the incidence of the disorder. Moreover, few studies have estimated the prevalence of BN among children and adolescents.

### Etiology

Historically, like AN, BN has been conceptualized as having sociocultural origins. Substantial familial aggregation of BN has been reported.^39^ Twin studies reveal a moderate to substantial contribution of additive genetic factors (between 54 percent and 83 percent) and unique environmental factors to BN.^81,^ ^82^ Linkage analyses have identified areas on chromosome 10p that may be implicated in BN.^83^ Numerous candidate genes have been studied for their role in risk for the disorder.^46^

Ongoing biological studies suggest fundamental disturbances in serotonergic function in individuals with BN.^80,^ ^84^ The ultimate understanding of the etiology of BN and of other disturbances that contribute to the development of inappropriate responses to satiety clues^85^ will most likely include main effects of both biological and environmental factors as well as their interactions and correlations.

### Course of Illness

Although BN is not typically associated with the serious physical complications normally associated with AN, patients commonly report physical symptoms such as fatigue, lethargy, bloating, and gastrointestinal problems. Individuals with BN who engage in frequent vomiting may experience electrolyte abnormalities, metabolic alkalosis, erosion of dental enamel, swelling of the parotid glands, and scars and calluses on the backs of their hands.^86^ Those who frequently misuse laxatives can have edema, fluid loss and subsequent dehydration, electrolyte abnormalities, metabolic acidosis, and potentially permanent loss of normal bowel function.^86^ Chapter 6 reviews eating-related, psychological, and biomarker-measured outcomes of BN in detail.

### Treatment

In the United States, most treatment for BN is conducted on an outpatient basis. Given the frequency of medical^87^ and nutritional complications, a comprehensive medical evaluation is the typical first step in treatment. Thereafter, psychotherapy, delivered either individually or in group format, is usually the cornerstone of BN interventions. Common approaches include cognitive-behavioral therapy and interpersonal psychotherapy. In cases in which the individual is experiencing medical complications of BN, is pregnant, or is unable to bring an entrenched binge-purge cycle under control on an outpatient basis, partial hospitalization or inpatient treatment is often warranted.

In 1996, the Food and Drug Administration (FDA) approved fluoxetine for the treatment of BN. Currently, this is the only FDA-approved medication for the treatment of any eating disorder.

## Eating Disorders Not Otherwise Specified (Binge Eating Disorder)

### Clinical Characteristics

Eating disorders not otherwise specified (EDNOS) is a diagnostic category that captures those individuals with eating disorders who do not meet criteria for AN or BN. The DSM IV lists six different examples of presentations of EDNOS:

1 all features of AN except amenorrhea;
2 all features of AN except remaining in a normal weight range;
3 all criteria for BN except frequency of binge eating or purging or duration of 3 months;
4 regular inappropriate compensatory behavior after eating small amounts of food;
5 chewing and spitting out food; and
6 binge eating disorder (BED).

Clinical reports suggest that individuals with EDNOS constitute the majority of individuals seeking professional help for an eating disorder.^88,^ ^89^ This suggests that the nomenclature for eating disorders is imperfect. Moreover, our attempts to address the key questions of this evidence report for the global category of EDNOS indicated a paucity of investigations on the nature of the highly heterogeneous category of EDNOS and on the treatment and outcome of specific presentations of EDNOS. We redirected the task to focus on BED, the one category of EDNOS that has a corpus of research.

### Diagnostic Criteria

The symptom of binge eating was first recognized in a subset of obese individuals by Stunkard in 1959.^90^ BED has had a slow and controversial evolution in the psychiatric nosology for eating disorders.^91^–^94^ DSM IV currently includes BED as a disorder requiring further study.

The DSM IV criteria appear in Table 3. Individuals with BED engage in regular binge eating behavior. A binge eating episode is determined in the same manner as in BN; it requires consumption of an unusually large amount of food and a sense of being out of control. The frequency criterion of twice per week is the same as in BN, although this criterion is not well supported by the literature.^95,^ ^96^ Unlike BN, individuals with BED do not regularly engage in compensatory behaviors. Several other criteria in the provisional BED diagnosis require further empirical support.

Table 3 Diagnostic criteria: binge eating disorder

Diagnostic Criteria
DSM IV Criteria for Binge Eating Disorder (307.50) | A Recurrent episodes of binge eating. An episode of binge eating is characterized by both of the following:; (1) Eating, in a discrete period of time (e.g., within any 2-hour period), an amount of food that is definitely larger than most people would eat in a similar period of time under similar circumstances; (2) The sense of lack of control over eating during the episode (e.g., a feeling that one cannot stop eating or control what or how much one is eating); B Binge-eating episodes are associated with three (or more) of the following:; (1) eating much more rapidly than normal; (2) eating until feeling uncomfortably full; (3) eating large amounts of food when not feeling physically hungry; (4) eating along because of being embarrassed by how much one is eating; (5) feeling disgusted with oneself, depressed, or very guilty after overeating; C Marked distress regarding binge eating is present; D The binge eating occurs, on average, at least 2 days a week for 6 months Note: The method of determining frequency differs from that used for bulimia nervosa; future research should address whether the preferred method of setting a frequency threshold is counting the number of days on which binges occur or counting the number of episodes of binge eating; E The binge eating is not associated with the regular use of inappropriate compensatory behavior (e.g., purging, fasting, excessive exercise, etc.) and does not occur exclusively during the course of anorexia nervosa or bulimia nervosa

DSM, Diagnostic and Statistical Manual.

### Epidemiology

Population-based studies suggest that between 0.7 percent and 3 percent of individuals in community samples meet criteria for BED.^92,^ ^97^–^99^ Community studies of obese individuals have found a prevalence of BED between 5 percent and 8 percent.^100,^ ^101^ Population-based studies of BED and the component behavior of binge eating report a relatively equal gender distribution,^92,^ ^99^ few differences in prevalence across races or ethnic groups,^102^ and possibly increased risk associated with lower socioeconomic status.^103,^ ^104^ In a population-based study of female twins, 37 percent of obese women (BMI ≥ 30) endorsed the symptom of binge eating,^105^ representing 2.7 percent of the female population studied.

### Etiology

In a community-based case-control study, Fairburn et al.^106^ found significant differences in exposure to risk factors between women with BED and healthy controls, but surprisingly few differences between women with BED and BN. In comparison to healthy controls, women with BED reported greater adverse childhood experiences, parental depression, personal vulnerability to depression, and exposure to negative comments about weight, shape, and eating.

BED has been shown to aggregate in families.^107^ Although heritability estimates for frank BED are not yet available, the heritability of binge eating in the absence of compensatory behaviors has been estimated to be 41 percent.^108^ In addition, binge eating has been explored as a potential intermediate behavioral phenotype in understanding the genetics of obesity. It has also been preliminarily identified in some studies as an important phenotypic characteristic of individuals with a mutation in the melanocortin 4 receptor (MC4R), a candidate gene that influences eating behavior,^109^ although this finding has not been replicated.^110^

### Course of Illness

Given that BED has only recently entered the psychiatric nomenclature, we have minimal population-based data on morbidity and mortality. The presence of binge eating or BED in obese individuals carries substantial risk. Obese individuals with binge eating or BED in clinical and community studies report earlier onsets of obesity and dieting,^92,^ ^111,^ ^112^ greater weight fluctuations,^112^ more cognitive features of disordered eating,^113^ lower self-esteem and self-efficacy,^114^ and higher scores on depression indices.^114^–^117^ Chapter 6 reviews eating-related, psychological, and biomarker-measured outcomes of BED in detail.

### Treatment

In the United States, treatment for BED is typically conducted on an outpatient basis. Psychological and dietary interventions aim to reduce binge eating and control weight.^118^ Common psychotherapeutic approaches include cognitive-behavioral and interpersonal psychotherapy; nutritional approaches include very low calorie diets and behavioral self-management strategies.^118^ Pharmacotherapy targeting both the core symptoms of binge eating and weight loss are also available as off-label interventions.^119^

## Production of This Evidence Report

### Organization

Given that eating disorders are an important public health problem, the Agency for Healthcare Research and Quality (AHRQ), the National Institutes of Health's Office of Research on Women's Health, together with the Health Resources and Services Administration (HRSA), and in consultation with National Institute of Mental Health (NIMH), commissioned an evidence report through its Evidence Based Practice Program and assigned it to the RTI International-University of North Carolina Evidence-Based Practice Center (RTI-UNC EPC). The issue is also of particular concern to the American Psychiatric Association and the Laureate Psychiatric Clinic and Hospital, which nominated the topic.

Chapter 2 describes our methodological approach, including the development of key questions and their analytic framework, our search strategies, and inclusion/exclusion criteria. In Chapters 3 through 5, we separately present the results of our literature search and synthesis on the treatment of each disease (respectively, AN, BN, and BED). Chapter 6 documents our findings about outcomes associated with each disease. Chapter 7 further discusses our findings, grades the strength of the bodies of literature, highlights methodological shortcomings of the extant research, and offers recommendations for future research. Appendixes (available electronically at http://www.ahrq.gov provide a detailed description of our search strings (Appendix A *), our quality rating forms (Appendix B), detailed evidence tables (Appendix C), list of excluded studies (Appendix D), and acknowledgments including our Technical Expert Panel and peer reviewers (Appendix E).

* Appendixes cited in this report are provided electronically athttp://www.ahrq.gov/downloads/pub/evidence/pdf/eatingdisorders/eatdis.pdf.

### Technical Expert Panel

We identified experts in the field of eating disorders to provide assistance throughout the project. The Technical Expert Panel (TEP) (seeAppendix E) contributes to AHRQ's broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of this product. The TEP served as both a resource and sounding board during the project. Our TEP comprised 10 individuals: three psychiatrists and two psychologists with eating disorder expertise; two nurses; one pediatric/adolescent medicine physician; one nutritionist; and one patient advocate.

To ensure accountability and scientifically relevant work, the TEP was called upon to provide guidance at all stages of the project. TEP members participated in conference calls and e-mail exchanges to

- refine the analytic framework and key questions at the beginning of the project;
- refine the scope of the project; and
- discuss inclusion and exclusion criteria.

Because of their extensive knowledge of the literature on eating disorders, including numerous articles authored by TEP members, and their active involvement in professional organizations and as practitioners in the field, we also asked TEP members to participate in external peer review of the draft report.

### Uses of This Report

We anticipate this report will be of value to members of the various professional organizations who treat eating disorders. These include the Academy for Eating Disorders, American Academy of Pediatrics, American Academy of Family Practice, American College of Obstetricians and Gynecologists, American Dietetics Association, American Psychiatric Association, American Psychological Association, International Association of Eating Disorders Professionals, National Association of Social Workers, and Society for Adolescent Medicine.

More generally, the report will assist these organizations in their mission to inform and educate practitioners. From this review, the National Institutes of Health can identify serious gaps in the research on eating disorders to guide funding policy. It can inform practitioners on the current evidence about outcomes associated with having these eating disorders and treating patients with them. Researchers will benefit from the concise analysis of the current status of the field, which will enable them to design future studies to address deficiencies in the field. Health educators can use this report to improve health communication. Finally, policymakers can use this report to allocate resources toward future research and initiatives that are likely to be successful.