# Appendix E. Acknowledgments

This study was supported by Contract 290-02-0016 from the Agency for Healthcare Research and Quality (AHRQ), Task No. 7. We acknowledge the continuing support of Kenneth Fink, J.D., M.A., former Director of the AHRQ Evidence-Based Practice Center (EPC) Program, and Marian D. James, Ph.D., M.A., the AHRQ Task Order Officer for this project.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina (UNC). From UNC, we thank EPC Co-Director, Timothy S. Carey, M.D., M.P.H.; EPC Literature Search Specialist, B. Lynn Whitener, Ph.D., and Leah Randolph, M.A., and Laura Morgan, M.A., Research Assistants. We would like to thank the abstractors: Jennifer Best, Ph.D., Jennifer McDuffie, Ph.D., Thomas Raney, Ph.D., Lauren Reba, B.A., Jennifer Shapiro, Ph.D., and Hemal Shroff, Ph.D. We also acknowledge assistance from Kelly Beth Bowker and Michele Crisafuli. We express our gratitude to Loraine Monroe, EPC word processing specialist, at RTI International.

## Technical Expert Panel

We extend our appreciation to the members of our Technical Expert Panel (TEP), who provided advice and input during our research process. The RTI-UNC EPC team solicited the views of TEP members from the beginning of the project. TEP members also provided insights into and reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEP members participated in refining the analytic framework and key questions and discussing the preliminary assessment of the literature, including inclusion/exclusion criteria, and also provided input on the information and categories, including evidence tables. The TEP was both a substantive resource and a “sounding board” throughout the study. It was also the body from which expertise was formally sought at several junctions. TEP members are listed below:

- Lisa Begg, Dr. P.H., R.N.
- Director of Research Programs
- Office of Research on Women's Health

- Mark Chavez, Ph.D.
- Associate Director, Research Training and Career Development Program
- Chief of the Sleep, Mood, and eating Disorders Program Chief of the Side Effects of Psychiatric Therapeutics Program Division of Adult Translational Research and Treatment Development National Institute of Mental Health National Institutes of Health

- Mary Gee
- Chair, Family Action Council Eating Disorder Center

- Craig L. Johnson, Ph.D.
- Director, Eating Disorders Program
- Laureate Psychiatric Clinic and Hospital

- Richard E. Kreipe, M.D.
- Chief of Adolescent Medicine, University of Rochester
- Society for Adolescent Medicine Representative

- James Lock, M.D., Ph.D.
- Associate Professor of Child Psychiatry and Pediatrics
- Stanford University School of Medicine
- Director, Eating Disorders Program for Children and Adolescents
- Lucile Salter Packard Children's Hospital At Stanford

- Marsha D. Marcus, Ph.D.
- Director, University of Pittsburgh Eating Disorders Program
- Cheryl L. Rock, Ph.D., R.D.
- Professor, Department of Family and Preventive Medicine
- University of California, San Diego

- Mary Tantillo, Ph.D., R.N.
- Clinical Associate
- University of Rochester
- Director of Eating Disorders Program
- Unity Health System
- Dept of Psychiatry and Behavioral Health

- B. Timothy Walsh, M.D.
- Director, Eating Disorder Research Unit
- New York State Psychiatric Institute

- Joel Yager, M.D.
- Psychiatrist, University of New Mexico
- American Psychiatric Representative

## Peer Reviewers

We submitted this report to external peer review to experts in the field. The names and affiliations of peer reviewers are listed below:

- Paula Adams Hillard, M.D.
- American College of Obstetricians and Gynecologists

- Lisa Begg, Dr. P.H., R.N.
- Director of Research Programs
- Office of Research on Women's Health

- Mark Chavez, Ph.D.
- Associate Director, Research Training and Career Development Program
- Chief of the Sleep, Mood, and eating Disorders Program Chief of the Side Effects of Psychiatric Therapeutics Program Division of Adult Translational Research and Treatment Development National Institute of Mental Health National Institutes of Health

- Jeanine Cogan, Ph.D.
- Policy Director, Eating Disorders Coalition

- Scott Crow, MD, F.A.E.D.
- Academy of Eating Disorders

- Mary Gee
- Chair, Family Action Council Eating Disorder Center

- David Herzog
- Psychiatrist and Pediatrician
- Director, Harvard Eating Disorders Center
- Past President, Eating Disorders Coalition

- Craig L. Johnson, Ph.D.
- Director, Eating Disorders Program
- Laureate Psychiatric Clinic and Hospital

- Ellen Kerber, M.D.
- Vice President, Anna Westin Foundation

- Richard E. Kreipe, M.D.
- Chief of Adolescent Medicine, University of Rochester
- Society for Adolescent Medicine Representative

- James Lock, M.D., Ph..D.
- Associate Professor of Child Psychiatry and Pediatrics
- Stanford University School of Medicine and Director, Eating Disorders Program for Children and Adolescents
- Lucile Salter Packard Children's Hospital At Stanford

- Marsha D. Marcus, Ph.D.
- Director, University of Pittsburgh Eating Disorders Program

- Sabrina Matoff-Stepp, M.A.
- Director, HRSA Office of Women's Health

- Kimberly McCallum, M.D.
- Board of Directors, International Association for Eating Disorder Professionals

- James Mitchell, M.D.
- Chairman, Department of Neuroscience
- President, Neuropsychiatric Research Institute Fargo, ND

- Pauline Powers, M.D.
- President, National Eating Disorders Association

- Sarah Pritts, M.D.
- American Academy of Family Practice

- Ruth Streigel-Moore, Ph.D.
- Co-Chair, Wesleyan University F.A.E.D.

- Mary Tantillo, Ph.D., R.N.
- Director, Unity Eating Disorders Program

- B. Timothy Walsh, M.D.
- Director, Eating Disorder Research Unit
- New York State Psychiatric Institute

- Joel Yager, M.D.
- Psychiatrist, University of New Mexico
- American Psychiatric Representative

- Susan Yanovski, M.D.
- Director, National Institute of Diabetes and Digestive and Kidney Diseases