# Appendix D. List of Excluded Articles

## Excluded Articles

Full Text Article Exclusion Criteria Codes for Database

X1 | Sample size too small
X2 | No control or comparison group
X3 | No original data (e.g., letters, reviews, etc.)
X4 | Does not focus on subjects with primary problem of AN, BN, BED
X5 | Study published in abstract form only
X6 | Wrong study design (e.g., case series only)
X7 | Wrong (or no) outcome
X8 | Insufficient statistical analysis to make comparisons
X9 | Wrong year (i.e., outside of our inclusion period of 1980-2005)
X10 | Drug no longer on the market
X11 | Uses DSM-III definition for BN
X12 | Does not follow individuals (AN or BED) for at least 1 year
X13 | Does not follow BN patients 3 months
XL | Not retrievable from library

## Excludes

Abraham S. Sexuality and reproduction in bulimia nervosa patients over 10 years. J Psychosom Res. 1998;44(34):491-502. Call Number: Reason for exclusion: X1. [pmid: 9587891].
Adami GF, Meneghelli A, Scopinaro N. Night eating and binge eating disorder in obese patients. Int J Eat Disord. 1999;25(3):335-8. Call Number: Reason for exclusion: X1. [pmid: 10191999].
Affenito SG, Lammi-Keefe CJ, Vogel S, et al. Women with insulin-dependent diabetes mellitus (IDDM) complicated by eating disorders are at risk for exacerbated alterations in lipid metabolism. Eur J Clin Nutr. 1997;51(7):462-6. Call Number: Reason for exclusion: X4. [pmid: 9234029].
Agras WS, Crow SJ, Halmi KA, et al. Outcome predictors for the cognitive behavior treatment of bulimia nervosa: data from a multisite study. Am J Psychiatry. 2000;157(8):1302-8. Call Number: Reason for exclusion: X2. [pmid: 10910795].
Agras WS, Dorian B, Kirkley BG, et al. Imipramine in the treatment of bulimia: a double-blind controlled study. Int J Eating Disorders. 1987;6(1):29-38. Call Number: Reason for exclusion: X1.
Alger SA, Schwalberg MD, Bigaouette JM, et al. Effect of a tricyclic antidepressant and opiate antagonist on binge-eating behavior in normoweight bulimic and obese, binge-eating subjects. Am J Clin Nutr. 1991;53(4):865-71. Call Number: Reason for exclusion: X1. [pmid: 2008865].
Ames-Frankel J, Devlin MJ, Walsh BT, et al. Personality disorder diagnoses in patients with bulimia nervosa: clinical correlates and changes with treatment. J Clin Psychiatry. 1992;53(3):90-6. Call Number: Reason for exclusion: X1. [pmid: 1548251].
Anderson CB, Joyce PR, Carter FA, et al. The effect of cognitive-behavioral therapy for bulimia nervosa on temperament and character as measured by the temperament and character inventory. Compr Psychiatry. 2002;43(3):182-8. Call Number: Reason for exclusion: X2. [pmid: 11994835].
Anderson KP, LaPorte DJ, Brandt H, et al. Sexual abuse and bulimia: response to inpatient treatment and preliminary outcome. J Psychiatr Res. 1997;31(6):621-33. Call Number: Reason for exclusion: X12. [pmid: 9447567].
Andrewes DG, O'Connor P, Mulder C, et al. Computerised psychoeducation for patients with eating disorders. Aust N Z J Psychiatry. 1996;30(4):492-7. Call Number: Reason for exclusion: X8. [pmid: 8887699].
Andrews B, Valentine ER, Valentine JD. Depression and eating disorders following abuse in childhood in two generations of women. Br J Clin Psychol. 1995;34(Pt 1):37-52. Call Number: Reason for exclusion: X1. [pmid: 7757038].
Bachar E, Latzer Y, Kreitler S, et al. Empirical comparison of two psychological therapies. Self psychology and cognitive orientation in the treatment of anorexia and bulimia. J Psychother Pract Res. 1999;8(2):115-28. Call Number: Reason for exclusion: X1. [pmid: 10079459].
Baell WK, Wertheim EH. Predictors of outcome in the treatment of bulimia nervosa. Br J Clin Psychol. 1992;31(Pt 3):330-2. Call Number: Reason for exclusion: X12. [pmid: 1393162].
Bara-Carril N, Williams CJ, Pombo-Carril MG, et al. A preliminary investigation into the feasibility and efficacy of a CD-ROM-based cognitive-behavioral self-help intervention for bulimia nervosa. Int J Eat Disord. 2004;35(4):538-48. Call Number: Reason for exclusion: X6. [pmid: 15101069].
Barbarich NC, McConaha CW, Gaskill J, et al. An open trial of olanzapine in anorexia nervosa. J Clin Psychiatry. 2004;65(11):1480-2. Call Number: Reason for exclusion: X2. [pmid: 15554759].
Barkmeier WW, Peterson DS, Wood LW. Anorexia nervosa: recognition and management. J Oral Med. 1982;37(2):33-7. Call Number: Reason for exclusion: X1. [pmid: 6213746].
Barlow J, Blouin J, Blouin A, et al. Treatment of bulimia with desipramine: a double-blind crossover study. Can J Psychiatry. 1988;33(2):129-33. Call Number: Reason for exclusion: X11. [pmid: 3284630].
Bean P, Loomis CC, Timmel P, et al. Outcome variables for anorexic males and females one year after discharge from residential treatment. J Addict Dis. 2004;23(2):83-94. Call Number: Reason for exclusion: X1. [pmid: 15132344].
Bergh C, Brodin U, Lindberg G, et al. Randomized controlled trial of a treatment for anorexia and bulimia nervosa. Proc Natl Acad Sci U S A. 2002;99(14):9486-91. Call Number: Reason for exclusion: X8. [pmid: 12082182]. [pmcid: 123167].
Bjorck C, Clinton D, Sohlberg S, et al. Interpersonal profiles in eating disorders: ratings of SASB self-image. Psychol Psychother. 2003;76(Pt 4):337-49. Call Number: Reason for exclusion: X6. [pmid: 14670185].
Blais MA, Becker AE, Burwell RA, et al. Pregnancy: outcome and impact on symptomatology in a cohort of eating-disordered women. Int J Eat Disord. 2000;27(2):140-9. Call Number: Reason for exclusion: X7. [pmid: 10657887].
Blouin AG, Blouin JH, Iversen H, et al. Light therapy in bulimia nervosa: a double-blind, placebo-controlled study. Psychiatry Res. 1928;60(1):1-9. Call Number: Reason for exclusion: X1.
Blouin AG, Blouin JH, Perez EL, et al. Treatment of bulimia with fenfluramine and desipramine. J Clin Psychopharmacol. 1988;8(4):261-9. Call Number: Reason for exclusion: X1. [pmid: 3062043].
Blouin J, Blouin A, Perez E, et al. Bulimia: independence of antibulimic and antidepressant properties of desipramine. Can J Psychiatry. 1989;34(1):24-9. Call Number: Reason for exclusion: X1. [pmid: 2647270].
Blouin JH, Carter J, Blouin AG, et al. Prognostic indicators in bulimia nervosa treated with cognitive-behavioral group therapy. Int J Eat Disord. 1994;15(2):113-23. Call Number: Reason for exclusion: X12. [pmid: 8173557].
Bossert S, Laessle RG, Meiller C, et al. Visual palatability of food in patients with eating disorders and dieting women. Behav Res Ther. 1991;29(4):337-41. Call Number: Reason for exclusion: X1. [pmid: 1888323].
Bossert S, Schmolz U, Wiegand M, et al. Predictors of short-term treatment outcome in bulimia nervosa inpatients. Behav Res Ther. 1992;30(2):193-9. Call Number: Reason for exclusion: X1. [pmid: 1567348].
Bossert S, Schnabel E, Krieg JC. Effects and limitations of cognitive behavior therapy in bulimia inpatients. Psychother Psychosom. 1989;51(2):77-82. Call Number: Reason for exclusion: X1. [pmid: 2626528].
Box J, Arnold LE, Smeltzer DJ. Protriptyline weight loss in compulsive eaters: a placebo-controlled study. J Psychiat Treat Eval. 1983;5:387-91. Call Number: Reason for exclusion: X4.
Brambilla F, Brunetta M, Draisci A, et al. T-lymphocyte concentrations of cholecystokinin-8 and beta-endorphin in eating disorders: II. Bulimia nervosa. Psychiatry Res. 1929;59(12):51-6. Call Number: Reason for exclusion: X7.
Brambilla F, Brunetta M, Peirone A, et al. T-lymphocyte cholecystokinin-8 and beta-endorphin concentrations in eating disorders: I. Anorexia nervosa. Psychiatry Res. 1929;59(12):43-50. Call Number: Reason for exclusion: X7.
Brambilla F, Draisci A, Peirone A, et al. Combined cognitive-behavioral, psychopharmacological and nutritional therapy in bulimia nervosa. Neuropsychobiology. 1995;32(2):68-71. Call Number: Reason for exclusion: X1. [pmid: 7477802].
Bretz WA, Krahn DD, Drury M, et al. Effects of fluoxetine on the oral environment of bulimics. Oral Microbiol Immunol. 1993;8(1):62-4. Call Number: Reason for exclusion: X6. [pmid: 8510986].
Brinch M, Isager T, Tolstrup K. Anorexia nervosa and motherhood: reproduction pattern and mothering behavior of 50 women. Acta Psychiatr Scand. 1988;77(5):611-7. Call Number: Reason for exclusion: X7. [pmid: 3269214].
Bulik CM, Sullivan PF, Carter FA, et al. Initial manifestations of disordered eating behavior: dieting versus binging. Int J Eat Disord. 1997;22(2):195-201. Call Number: Reason for exclusion: X7. [pmid: 9261659].
Bulik CM, Sullivan PF, Carter FA, et al. Predictors of rapid and sustained response to cognitive-behavioral therapy for bulimia nervosa. Int J Eat Disord. 1999;26(2):137-44. Call Number: Reason for exclusion: X8. [pmid: 10422602].
Bulik CM, Sullivan PF, Fear JL, et al. Fertility and reproduction in women with anorexia nervosa: a controlled study. J Clin Psychiatry. 1999;60(2):130-5. quiz 135–7. Call Number: Reason for exclusion: X7. [pmid: 10084645].
Cachelin FM, Striegel-Moore RH, Elder KA, et al. Natural course of a community sample of women with binge eating disorder. Int J Eat Disord. 1999;25(1):45-54. Call Number: Reason for exclusion: X12. [pmid: 9924652].
Carter FA, Bulik CM, McIntosh VV, et al. Changes in cue reactivity following treatment for bulimia nervosa. Int J Eat Disord. 2001;29(3):336-44. Call Number: Reason for exclusion: X2. [pmid: 11262514].
Carter FA, Bulik CM, McIntosh VV, et al. Cue reactivity as a predictor of outcome with bulimia nervosa. Int J Eat Disord. 2002;31(3):240-50. Call Number: Reason for exclusion: X6. [pmid: 11920985].
Carter FA, McIntosh VV, Frampton CM, et al. Predictors of childbirth following treatment for bulimia nervosa. Int J Eat Disord. 2003;34(3):337-42. Call Number: Reason for exclusion: X7. [pmid: 12949925].
Carter FA, McIntosh VV, Joyce PR, et al. Abstention during cue reactivity assessment is associated with better outcome among women with bulimia nervosa. Eating Behaviors. 2001;2(3):273-8. Call Number: Reason for exclusion: X6. [pmid: 15001036].
Carter FA, McIntosh VV, Joyce PR, et al. Bulimia nervosa, childbirth, and psychopathology. J Psychosom Res. 2003;55(4):357-61. Call Number: Reason for exclusion: X7. [pmid: 14507547].
Carter FA, McIntosh VV, Joyce PR, et al. Patterns of weight change after treatment for bulimia nervosa. Int J Eat Disord. 2004;36(1):12-21. Call Number: Reason for exclusion: X6. [pmid: 15185267].
Ceccherini-Nelli A, Guidi L. Fluoxetine: the relationship between response, adverse events, and plasma concentrations in the treatment of bulimia nervosa. Int Clin Psychopharmacol. 1993;8(4):311-3. Call Number: Reason for exclusion: X6. [pmid: 8277153].
Clinton DN, Glant R. The eating disorders spectrum of DSM-III-R. Clinical features and psychosocial concomitants of 86 consecutive cases from a Swedish urban catchment area. J Nerv Ment Dis. 1992;180(4):244-50. Call Number: Reason for exclusion: X12. [pmid: 1556564].
Collings S, King M. Ten-year follow-up of 50 patients with bulimia nervosa. Br J Psychiatry. 1994;164(1):80-7. Call Number: Reason for exclusion: X1. [pmid: 8137114].
Crisp AH. Gastrointestinal disturbance in anorexia nervosa. Postgrad Med J. 1985;61(711):3-5. Call Number: Reason for exclusion: X3. [pmid: 3991398].
Dalvit-McPhillips S. A dietary approach to bulimia treatment. Physiology & Behavior. 1984;33(5):769-75. Call Number: Reason for exclusion: X1. [pmid: 6395153].
Davis BA, Kennedy SH, Durden DA, et al. The effect of the MAO-A selective inhibitor brofaromine on the plasma and urine concentrations of some biogenic amines and their acidic metabolites in bulimia nervosa. Prog Neuropsychopharmacol Biol Psychiatry. 1993;17(5):747-63. Call Number: Reason for exclusion: X1. [pmid: 7504824].
de Groot JM, Rodin G, Olmsted MP. Alexithymia, depression, and treatment outcome in bulimia nervosa. Compr Psychiatry. 1995;36(1):53-60. Call Number: Reason for exclusion: X1. [pmid: 7705088].
de la Piedra C, Calero JA, Traba ML, et al. Urinary alpha and beta C-telopeptides of collagen I: clinical implications in bone remodeling in patients with anorexia nervosa. Osteoporos Int. 1999;10(6):480-6. Call Number: Reason for exclusion: X1. [pmid: 10663349].
de Zwaan M, Nutzinger DO, Schoenbeck G. Binge eating in overweight women. Compr Psychiatry. 1992;33(4):256-61. Call Number: Reason for exclusion: X4. [pmid: 1643867].
Deter HC, Kopp W, Zipfel S, et al. [Male anorexia nervosa patients in long-term follow-up]. Nervenarzt. 1998;69(5):419-26. Call Number: Reason for exclusion: X1. [pmid: 9629558].
Eckert ED, Goldberg SC, Halmi KA, et al. Behaviour therapy in anorexia nervosa. Br J Psychiatry. 1979;134:55-9. Call Number: Reason for exclusion: X9. [pmid: 760924].
Fahy TA, Eisler I, Russell GF. A placebo-controlled trial of d-fenfluramine in bulimia nervosa. Br J Psychiatry. 1993;162:597-603. Call Number: Reason for exclusion: X10. [pmid: 8149110].
Fairburn CG, Kirk J, O'Connor M, et al. A comparison of two psychological treatments for bulimia nervosa. Behav Res Ther. 1986;24(6):629-43. Call Number: Reason for exclusion: X1. [pmid: 3800834].
Fichter MM, Quadflieg N, Rief W. Course of multi-impulsive bulimia. Psychol Med. 1994;24(3):591-604. Call Number: Reason for exclusion: X1. [pmid: 7991741].
Field AE, Austin SB, Taylor CB, et al. Relation between dieting and weight change among preadolescents and adolescents. Pediatrics. 2003;112(4):900-6. Call Number: Reason for exclusion: X4. [pmid: 14523184].
Field T, Schanberg S, Kuhn C, et al. Bulimic adolescents benefit from massage therapy. Adolescence. 1998;33(131):555-63. Call Number: Reason for exclusion: X1. [pmid: 9831872].
Franzoni F, Mataloni E, Femia R, et al. Effect of oral potassium supplementation on QT dispersion in anorexia nervosa. Acta Paediatr. 2002;91(6):653-6. Call Number: Reason for exclusion: X7. [pmid: 12162596].
Freeman C. Day patient treatment for anorexia nervosa. British Review of Bulimia and Anorexia Nervosa. 1992;6(1):3-8. Call Number: Reason for exclusion: X3.
Freeman C, Sinclair F, Turnbull J, et al. Psychotherapy for bulimia: a controlled study. J Psychiatr Res. 1985;19(23):373-8. Call Number: Reason for exclusion: X11. [pmid: 3900361].
Freeman CP, Barry F, Dunkeld-Turnbull J, et al. Controlled trial of psychotherapy for bulimia nervosa. Br Med J (Clin Res Ed). 1988;296(6621):521-5. Call Number: Reason for exclusion: X11.
Gaillard M, Wulliemier F. [Comparative follow up study of 2 treatments for anorexia nervosa (classical approach and behavioral therapy)]. J Psychosom Res. 1982;26(2):113-21. Call Number: Reason for exclusion: X1. [pmid: 7077543].
Gaskill JA, Treat TA, McCabe EB, et al. Does olanzapine affect the rate of weight gain among inpatients with eating disorders?. Eating Disorders Review. 2001;12(6):1-2. Call Number: Reason for exclusion: X 14.
Gelber D, Levine J, Belmaker RH. Effect of inositol on bulimia nervosa and binge eating. Int J Eat Disord. 2001;29(3):345-8. Call Number: Reason for exclusion: X8. [pmid: 11262515].
Gendall KA, Bulik CM, Sullivan PF, et al. Body weight in bulimia nervosa. Eat Weight Disord. 1999;4(4):157-64. Call Number: Reason for exclusion: X6. [pmid: 10728175].
Gendall KA, Joyce PR, Carter FA, et al. Thyroid indices and treatment outcome in bulimia nervosa. Acta Psychiatr Scand. 2003;108(3):190-5. Call Number: Reason for exclusion: X7. [pmid: 12890273].
Ghaderi A, Scott B. Coping in dieting and eating disorders: a population-based study. J Nerv Ment Dis. 2000;188(5):273-9. Call Number: Reason for exclusion: X4. [pmid: 10830564].
Ghaderi A, Scott B. Prevalence, incidence and prospective risk factors for eating disorders. Acta Psychiatr Scand. 2001;104(2):122-30. Call Number: Reason for exclusion: X6. [pmid: 11473506].
Ghaderi A, Scott B. Pure and guided self-help for full and sub-threshold bulimia nervosa and binge eating disorder. Br J Clin Psychol. 2003;42(Pt 3):257-69. Call Number: Reason for exclusion: X1. [pmid: 14565892].
Goldberg SC, Casper RC, Eckert ED. Effects of cyproheptadine in anorexia nervosa. Psychopharmacol Bull. 1980;16(2):29-30. Call Number: Reason for exclusion: X8.
Goldberg SC, Halmi KA, Eckert ED, et al. Cyproheptadine in anorexia nervosa. Br J Psychiatry. 1979;134:67-70. Call Number: Reason for exclusion: X9. [pmid: 367480].
Goldbloom DS, Olmsted MP. Pharmacotherapy of bulimia nervosa with fluoxetine: assessment of clinically significant attitudinal change. Am J Psychiatry. 1993;150(5):770-4. Call Number: Reason for exclusion: X13. [pmid: 8480824].
Goodrick GK, Pendleton VR, Kimball KT, et al. Binge eating severity, self-concept, dieting self-efficacy and social support during treatment of binge eating disorder. Int J Eat Disord. 1999;26(3):295-300. Call Number: Reason for exclusion: X4. [pmid: 10441245].
Goodrick GK, Poston WS 2nd,, Kimball KT, et al. Nondieting versus dieting treatment for overweight binge-eating women. J Consult Clin Psychol. 1998;66(2):363-8. Call Number: Reason for exclusion: X4. [pmid: 9583339].
Gordon CM, Grace E, Emans SJ, et al. Effects of oral dehydroepiandrosterone on bone density in young women with anorexia nervosa: a randomized trial. J Clin Endocrinol Metab. 2002;87(11):4935-41. Call Number: Reason for exclusion: X7. [pmid: 12414853].
Gordon CM, Grace E, Emans SJ, et al. Changes in bone turnover markers and menstrual function after short-term oral DHEA in young women with anorexia nervosa. J Bone Miner Res. 1999;14(1):136-45. Call Number: Reason for exclusion: X7. [pmid: 9893076].
Greeno CG, Wing RR. A double-blind, placebo-controlled trial of the effect of fluoxetine on dietary intake in overweight women with and without binge-eating disorder. Am J Clin Nutr. 1996;64(3):267-73. Call Number: Reason for exclusion: X4. [pmid: 8780333].
Greeno CG, Wing RR, Marcus MD. Nocturnal eating in binge eating disorder and matched-weight controls. Int J Eat Disord. 1995;18(4):343-9. Call Number: Reason for exclusion: X1. [pmid: 8580920].
Griffiths RA, Channon-Little L. The hypnotizability of patients with bulimia nervosa and partial syndromes participating in a controlled treatment outcome study. Contemporary Hypnosis. 1993;10(10):81-7. Call Number: Reason for exclusion: X6.
Griffiths RA, Hadzi-Pavlovic D, Channon-Little L. The short-term follow-up effects of hypnobehavioural and cognitive behavioural treatment for bulimia nervosa. European Eating Disorders Review. 1996;4(1):12-31. Call Number: Reason for exclusion: X6.
Grilo CM, Sanislow CA, Shea MT, et al. The natural course of bulimia nervosa and eating disorder not otherwise specified is not influenced by personality disorders. Int J Eat Disord. 2003;34(3):319-30. Call Number: Reason for exclusion: X1. [pmid: 12949923].
Grinspoon S, Baum H, Lee K, et al. Effects of short-term recombinant human insulin-like growth factor I administration on bone turnover in osteopenic women with anorexia nervosa. J Clin Endocrinol Metab. 1996;81(11):3864-70. Call Number: Reason for exclusion: X7. [pmid: 8923830].
Grinspoon S, Miller K, Herzog D, et al. Effects of recombinant human insulin-like growth factor (IGF)-I and estrogen administration on IGF-I, IGF binding protein (IGFBP)-2, and IGFBP-3 in anorexia nervosa: a randomized-controlled study. J Clin Endocrinol Metab. 2003;88(3):1142-9. Call Number: Reason for exclusion: X7. [pmid: 12629097].
Grinspoon S, Thomas L, Miller K, et al. Effects of recombinant human IGF-I and oral contraceptive administration on bone density in anorexia nervosa. J Clin Endocrinol Metab. 2002;87(6):2883-91. Call Number: Reason for exclusion: X7. [pmid: 12050268].
Gross H, Ebert MH, Faden VB, et al. A double-blind trial of delta 9-tetrahydrocannabinol in primary anorexia nervosa. J Clin Psychopharmacol. 1983;3(3):165-71. Call Number: Reason for exclusion: X6. [pmid: 6308069].
Hall A, Slim E, Hawker F, et al. Anorexia nervosa: long-term outcome in 50 female patients. Br J Psychiatry. 1984;145:407-13. Call Number: Reason for exclusion: X1. [pmid: 6593109].
Halmi KA, Agras WS, Crow S, et al. Predictors of treatment acceptance and completion in anorexia nervosa: implications for future study designs. Arch Gen Psychiatry. 2005;62(7):776-81. Call Number: Reason for exclusion: X6. [pmid: 15997019].
Halmi KA, Agras WS, Mitchell J, et al. Relapse predictors of patients with bulimia nervosa who achieved abstinence through cognitive behavioral therapy. Arch Gen Psychiatry. 2002;59(12):1105-9. Call Number: Reason for exclusion: X6. [pmid: 12470126].
Halmi KA, Falk JR. Anorexia nervosa. A study of outcome discriminators in exclusive dieters and bulimics. J Am Acad Child Psychiatry. 1982;21(4):369-75. Call Number: Reason for exclusion: X1. [pmid: 6956627].
Hartman BK, Faris PL, Kim SW, et al. Treatment of bulimia nervosa with ondansetron. Arch Gen Psychiatry. 1997;54(10):969-70. Call Number: Reason for exclusion: X1. [pmid: 9337778].
Hasler WL. 5-HT(3) antagonist therapy of bulimia nervosa: a peripherally active agent for a central nervous system eating disorder?. Gastroenterology. 2000;119(1):271-2. Call Number: Reason for exclusion: X1. [pmid: 10889184].
Heer M, Mika C, Grzella I, et al. Bone turnover during inpatient nutritional therapy and outpatient follow-up in patients with anorexia nervosa compared with that in healthy control subjects. Am J Clin Nutr. 2004;80(3):774-81. Call Number: Reason for exclusion: X1. [pmid: 15321821].
Hentschel F, Schmidbauer M, Detzner U, et al. [Reversible changes in brain volume in anorexia nervosa]. Z Kinder Jugendpsychiatr. 1995;23(2):104-12. Call Number: Reason for exclusion: X1. [pmid: 7785361].
Herzog DB, Sacks NR. Bulimia nervosa: comparison of treatment responders vs. nonresponders. Psychopharmacol Bull. 1993;29(1):121-5. Call Number: Reason for exclusion: X7. [pmid: 8378505].
Herzog T, Hartmann A. [Psychoanalytically oriented treatment of anorexia nervosa. Methodology-related critical review of the literature using meta-analysis methods]. Psychother Psychosom Med Psychol. 1997;47(910):299-315. Call Number: Reason for exclusion: X3. [pmid: 9411460].
Holtkamp K, Hebebrand J, Mika C, et al. High serum leptin levels subsequent to weight gain predict renewed weight loss in patients with anorexia nervosa. Psychoneuroendocrinology. 2004;29(6):791-7. Call Number: Reason for exclusion: X1. [pmid: 15110928].
Horne RL, Ferguson JM, Pope HG Jr,, et al. Treatment of bulimia with bupropion: a multicenter controlled trial. J Clin Psychiatry. 1988;49(7):262-6. Call Number: Reason for exclusion: X11. [pmid: 3134343].
Hotta M, Shibasaki T, Sato K, et al. The importance of body weight history in the occurrence and recovery of osteoporosis in patients with anorexia nervosa: evaluation by dual X-ray absorptiometry and bone metabolic markers. Eur J Endocrinol. 1998;139(3):276-83. Call Number: Reason for exclusion: X1. [pmid: 9758436].
Hsu LK, Clement L, Santhouse R, et al. Treatment of bulimia nervosa with lithium carbonate. A controlled study. J Nerv Ment Dis. 1991;179(6):351-5. Call Number: Reason for exclusion: X11. [pmid: 1904908].
Hudson JI, Pope HG Jr,, Jonas JM. Treatment of bulimia with antidepressants: theoretical considerations and clinical findings. Res Publ Assoc Res Nerv Ment Dis. 1984;62:259-73. Call Number: Reason for exclusion: X6. [pmid: 6420851].
Hudson JI, Pope HG Jr, Keck PE Jr, et al. Treatment of bulimia nervosa with trazodone: short-term response and long-term follow-up. Clin Neuropharmacol. 1989;12(Suppl 1):S38-46. Discussion S47-9. Call Number: Reason for exclusion: X6. [pmid: 2663152].
Hughes PL, Wells LA, Cunningham CJ, et al. Treating bulimia with desipramine. A double-blind, placebo-controlled study. Arch Gen Psychiatry. 1986;43(2):182-6. Call Number: Reason for exclusion: X1. [pmid: 3511878].
Imbierowicz K, Braks K, Jacoby GE, et al. High-caloric supplements in anorexia treatment. Int J Eat Disord. 2002;32(2):135-45. Call Number: Reason for exclusion: X6. [pmid: 12210655].
Jacobi C. [Pharmacotherapy and behavior therapy for anorexia and bulimia nervosa]. Verhaltenstherapie. 1994;4(3):162-71. Call Number: Reason for exclusion: X3.
Jeammet P, Jayle D, Terrasse-Brechon G, et al. [Outcome of anorexia nervosa]. Neuropsychiatr Enfance Adolesc. 1984;32(23):97-113. Call Number: Reason for exclusion: X6. [pmid: 6728139].
Jeffery RW, Sherwood NE, Brelje K, et al. Mail and phone interventions for weight loss in a managed-care setting: Weigh-To-Be one-year outcomes. Int J Obes Relat Metab Disord. 2003;27(12):1584-92. Call Number: Reason for exclusion: X4. [pmid: 14517547].
Johnson-Sabine E, Reiss D, Dayson D. Bulimia nervosa: a 5-year follow-up study. Psychol Med. 1992;22(4):951-9. Call Number: Reason for exclusion: X1. [pmid: 1488490].
Jonsson PH. [A study of patients with anorexia nervosa in Gavleborg. More boys than girls required intensive care]. Lakartidningen. 1917;98(42):4578-82. Call Number: Reason for exclusion: X8.
Katz RL, Keen CL, Litt IF, et al. Zinc deficiency in anorexia nervosa. J Adolesc Health Care. 1987;8(5):400-6. Call Number: Reason for exclusion: X6. [pmid: 3312133].
Katzman DK, Lambe EK, Mikulis DJ, et al. Cerebral gray matter and white matter volume deficits in adolescent girls with anorexia nervosa. J Pediatr. 1996;129(6):794-803. Call Number: Reason for exclusion: X1. [pmid: 8969719].
Kaye WH, Greeno CG, Moss H, et al. Alterations in serotonin activity and psychiatric symptoms after recovery from bulimia nervosa. Arch Gen Psychiatry. 1998;55(10):927-35. Call Number: Reason for exclusion: X1. [pmid: 9783564].
Keel PK, Dorer DJ, Eddy KT, et al. Predictors of treatment utilization among women with anorexia and bulimia nervosa. Am J Psychiatry. 2002;159(1):140-2. Call Number: Reason for exclusion: X6. [pmid: 11772705].
Keel PK, Mitchell JE, Davis TL, et al. Long-term impact of treatment in women diagnosed with bulimia nervosa. Int J Eat Disord. 2002;31(2):151-8. Call Number: Reason for exclusion: X11. [pmid: 11920976].
Keel PK, Mitchell JE, Miller KB, et al. Social adjustment over 10 years following diagnosis with bulimia nervosa. Int J Eat Disord. 2000;27(1):21-8. Call Number: Reason for exclusion: X7. [pmid: 10590445].
Kennedy SH, Piran N, Warsh JJ, et al. A trial of isocarboxazid in the treatment of bulimia nervosa. J Clin Psychopharmacol. 1988;8(6):391-6. Call Number: Reason for exclusion: X1. [pmid: 3069879].
Kingston K, Szmukler G, Andrewes D, et al. Neuropsychological and structural brain changes in anorexia nervosa before and after refeeding. Psychol Med. 1996;26(1):15-28. Call Number: Reason for exclusion: X12. [pmid: 8643754].
Kirkley BG, Schneider JA, Agras WS, et al. Comparison of two group treatments for bulimia. J Consult Clin Psychol. 1985;53(1):43-8. Call Number: Reason for exclusion: X1. [pmid: 3856582].
Korndorfer SR, Lucas AR, Suman VJ, et al. Long-term survival of patients with anorexia nervosa: a population-based study in Rochester, Minn. Mayo Clin Proc. 2003;78(3):278-84. Call Number: Reason for exclusion: X4. [pmid: 12630579].
Kreipe RE, Strauss J, Hodgman CH, et al. Menstrual cycle abnormalities and subclinical eating disorders: a preliminary report. Psychosom Med. 1989;51(1):81-6. Call Number: Reason for exclusion: X1. [pmid: 2928463].
Lacey JH, Crisp AH. Hunger, food intake and weight: the impact of clomipramine on a refeeding anorexia nervosa population. Postgrad Med J. 1980;56 Suppl 1:79-85. Call Number: Reason for exclusion: X8. [pmid: 6994086].
Lacey J. Bulimia nervosa, binge eating, and psychogenic vomiting: a controlled treatment study and long term outcome. Br Med J (Clin Res Ed). 1983;286(6378):1609-13. Call Number: Reason for exclusion: X11.
Laessle RG, Zoettle C, Pirke K. M. Meta-analysis of treatment studies for bulimia. Int J Eat Disord. 1987;6:647-54. Call Number: Reason for exclusion: X3.
Lee NF, Rush AJ. Cognitive-behavioral group therapy for bulimia. Int J Eat Disord. 1986;5:599-615. Call Number: Reason for exclusion: X11.
Leitenberg H, Rosen JC, Gross J, et al. Exposure plus response-prevention treatment of bulimia nervosa. J Consult Clin Psychol. 1988;56(4):535-41. Call Number: Reason for exclusion: X11. [pmid: 3198810].
Lewandowski LM, Gebing TA, Anthony JL, et al. Meta-analysis of cognitive-behavioral treatment studies for bulimia. Clin Psychol Rev. 1997;17(7):703-18. Call Number: Reason for exclusion: X3. [pmid: 9397333].
Liedtke R, Jäger B, Lempa W, et al. Therapy outcome of two treatment models for bulimia nervosa: preliminary results of a controlled study. Psychother Psychosom. 1991;56(12):56-63. Call Number: Reason for exclusion: X6. [pmid: 1891582].
Linde JA, Jeffery RW, Levy RL, et al. Binge eating disorder, weight control self-efficacy, and depression in overweight men and women. Int J Obes Relat Metab Disord. 2004;28(3):418-25. Call Number: Reason for exclusion: X4. [pmid: 14724662].
Loeb KL, Wilson GT, Gilbert JS, et al. Guided and unguided self-help for binge eating. Behav Res Ther. 2000;38(3):259-72. Call Number: Reason for exclusion: X8. [pmid: 10665159].
Lucas AR, Melton LJ3, Crowson CS, et al. Long-term fracture risk among women with anorexia nervosa: a population-based cohort study. Mayo Clin Proc. 1999;74(10):972-7. Call Number: Reason for exclusion: X4. [pmid: 10918862].
Maddocks SE, Kaplan AS, Woodside DB, et al. Two year follow-up of bulimia nervosa: the importance of abstinence as the criterion of outcome. Int J Eat Disord. 1990;12(2):133-41. Call Number: Reason for exclusion: X1.
Marcus MD, Wing RR, Ewing L, et al. A double-blind, placebo-controlled trial of fluoxetine plus behavior modification in the treatment of obese binge-eaters and non-binge-eaters. Am J Psychiatry. 1990;147(7):876-81. Call Number: Reason for exclusion: X4. [pmid: 2192563].
Marcus MD, Wing RR, Hopkins J. Obese binge eaters: affect, cognitions, and response to behavioural weight control. J Consult Clin Psychol. 1988;56(3):433-9. Call Number: Reason for exclusion: X1. [pmid: 3397436].
Mark EJ, Patalas ED, Chang HT, et al. Fatal pulmonary hypertension associated with short-term use of fenfluramine and phentermine. N Engl J Med. 1997;337(9):602-6. Call Number: Reason for exclusion: X6. [pmid: 9271482].
McCann UD, Agras WS. Successful treatment of nonpurging bulimia nervosa with desipramine: a double-blind, placebo-controlled study. Am J Psychiatry. 1990;147(11):1509-13. Call Number: Reason for exclusion: X1. [pmid: 2221164].
McCarthy MK, Goff DC, Baer L, et al. Dissociation, childhood trauma, and the response to fluoxetine in bulimic patients. Int J Eat Disord. 1994;15(3):219-26. Call Number: Reason for exclusion: X8. [pmid: 8199601].
McElroy SL, Shapira NA, Arnold LM, et al. Topiramate in the long-term treatment of binge-eating disorder associated with obesity. J Clin Psychiatry. 2004;65(11):1463-9. Call Number: Reason for exclusion: X6. [pmid: 15554757].
McKnight Investigators T. Risk factors for the onset of eating disorders in adolescent girls: results of the McKnight longitudinal risk factor study. Am J Psychiatry 2003;160(2):248–54. Call Number: Reason for exclusion: X6
Miller KK, Deckersbach T, Rauch SL, et al. Testosterone administration attenuates regional brain hypometabolism in women with anorexia nervosa. Psychiatry Res. 2004;132(3):197-207. Call Number: Reason for exclusion: X6. [pmid: 15664791].
Mitchell JE, Christenson G, Jennings J, et al. A placebo-controlled, double-blind crossover study of naltrexone hydrochloride in outpatients with normal weight bulimia. J Clin Psychopharmacol. 1989;9(2):94-7. Call Number: Reason for exclusion: X1. [pmid: 2656781].
Mitchell JE, Groat R. A placebo-controlled, double-blind trial of amitriptyline in bulimia. J Clin Psychopharmacol. 1984;4(4):186-93. Call Number: Reason for exclusion: X11. [pmid: 6381556].
Mitchell JE, Pyle R, Eckert ED, et al. The influence of prior alcohol and drug abuse problems on bulimia nervosa treatment outcome. Addict Behav. 1990;15(2):169-73. Call Number: Reason for exclusion: X11. [pmid: 2343791].
Mitchell JE, Pyle RL, Eckert ED, et al. Electrolyte and other physiological abnormalities in patients with bulimia. Psychol Med. 1983;13(2):273-8. Call Number: Reason for exclusion: X6. [pmid: 6192459].
Mitchell JE, Pyle RL, Eckert ED, et al. A comparison study of antidepressants and structured intensive group psychotherapy in the treatment of bulimia nervosa. Arch Gen Psychiatry. 1990;47(2):149-57. Call Number: Reason for exclusion: X11. [pmid: 2405806].
Mitchell JE, Pyle RL, Eckert ED, et al. Antidepressants vs. group therapy in the treatment of bulimia. Psychopharmacol Bull. 1987;23(1):41-4. Call Number: Reason for exclusion: X11. [pmid: 3602329].
Mitchell JE, Pyle RL, Pomeroy C, et al. Cognitive-behavioral group psychotherapy of bulimia nervosa: importance of logistical variables. Int J Eat Disord. 1993;14(3):277-87. Call Number: Reason for exclusion: X6. [pmid: 8275064].
Moorhead DJ, Stashwick CK, Reinherz HZ, et al. Child and adolescent predictors for eating disorders in a community population of young adult women. Int J Eat Disord. 2003;33(1):1-9. Call Number: Reason for exclusion: X6. [pmid: 12474194].
Mussell MP, Mitchell JE, Crosby RD, et al. Commitment to treatment goals in prediction of group cognitive-behavioral therapy treatment outcome for women with bulimia nervosa. J Consult Clin Psychol. 2000;68(3):432-7. Call Number: Reason for exclusion: X2. [pmid: 10883560].
Mussell MP, Mitchell JE, Weller CL, et al. Onset of binge eating, dieting, obesity, and mood disorders among subjects seeking treatment for binge eating disorder. Int J Eat Disord. 1995;17(4):395-401. Call Number: Reason for exclusion: X2. [pmid: 7620480].
Nauta H, Hospers H, Kok G, et al. A comparison between a cognitive and a behavioral treatment for obese binge eaters and obese non-binge eaters. Behavior Therapy. 2000;31(3):441-61. Call Number: Reason for exclusion: X4.
Negrao AB, Cordas TA. Clinical characteristics and course of anorexia nervosa in Latin America, a Brazilian sample. Psychiatry Res. 1916;62(1):17-21. Call Number: Reason for exclusion: X1.
Newton JR, Freeman CP, Hannan WJ, et al. Osteoporosis and normal weight bulimia nervosa--which patients are at risk?. J Psychosom Res. 1993;37(3):239-47. Call Number: Reason for exclusion: X1. [pmid: 8478818].
Norring CE, Sohlberg SS. Outcome, recovery, relapse and mortality across six years in patients with clinical eating disorders. Acta Psychiatr Scand. 1993;87(6):437-44. Call Number: Reason for exclusion: X1. [pmid: 8356896].
Nussbaum M, Shenker IR, Baird D, et al. Follow-up investigation in patients with anorexia nervosa. J Pediatr. 1985;106(5):835-40. Call Number: Reason for exclusion: X12. [pmid: 3998927].
Okamoto A, Yamashita T, Nagoshi Y, et al. A behavior therapy program combined with liquid nutrition designed for anorexia nervosa. Psychiatry Clin Neurosci. 2002;56(5):515-20. Call Number: Reason for exclusion: X6. [pmid: 12193240].
Olmsted MP, Daneman D, Rydall AC, et al. The effects of psychoeducation on disturbed eating attitudes and behavior in young women with type 1 diabetes mellitus. Int J Eat Disord. 2002;32(2):230-9. Call Number: Reason for exclusion: X4. [pmid: 12210667].
Olmsted MP, Davis R, Garner DM, et al. Efficacy of a brief group psychoeducational intervention for bulimia nervosa. Behav Res Ther. 1991;29(1):71-83. Call Number: Reason for exclusion: X6. [pmid: 2012591].
Olmsted MP, Kaplan AS, Rockert W. Defining remission and relapse in bulimia nervosa. Int J Eat Disord. 2005;38(1):1-6. Call Number: Reason for exclusion: X1. [pmid: 15971233].
Olmsted MP, Kaplan AS, Rockert W, et al. Rapid responders to intensive treatment of bulimia nervosa. Int J Eat Disord. 1996;19(3):279-85. Call Number: Reason for exclusion: X1. [pmid: 8704727].
Ordman AM, Kirschenbaum DS. Cognitive-behavioral therapy for bulimia: an initial outcome study. J Consult Clin Psychol. 1985;53(3):305-13. Call Number: Reason for exclusion: X1. [pmid: 3859502].
Palmer RL, Birchall H, McGrain L, et al. Self-help for bulimic disorders: a randomised controlled trial comparing minimal guidance with face-to-face or telephone guidance. Br J Psychiatry. 2002;181:230-5. Call Number: Reason for exclusion: X8. [pmid: 12204928].
Patton GC, Coffey C, Sawyer SM. The outcome of adolescent eating disorders: findings from the Victorian Adolescent Health Cohort Study. Eur Child Adolesc Psychiatry. 2003;12 Suppl 1:I25-9. Call Number: Reason for exclusion: X4. [pmid: 12567212].
Pertschuk MJ, Forster J, Buzby G, et al. The treatment of anorexia nervosa with total parenteral nutrition. Biol Psychiatry. 1981;16(6):539-50. Call Number: Reason for exclusion: X6. [pmid: 6789899].
Pope HG Jr,, Hudson JI, Jonas JM, et al. Antidepressant treatment of bulimia: a two-year follow-up study. J Clin Psychopharmacol. 1985;5(6):320-7. Call Number: Reason for exclusion: X6. [pmid: 3864795].
Pope HG Jr,, Hudson JI, Jonas JM, et al. Bulimia treated with imipramine: a placebo-controlled, double-blind study. Am J Psychiatry. 1983;140(5):554-8. Call Number: Reason for exclusion: X1. [pmid: 6342421].
Porzelius LK, Houston C, Smith M, et al. Comparison of a standard behavioral weight loss treatment and a binge eating weight loss treatment. Behavior Therapy. 1995;26:119-34. Call Number: Reason for exclusion: X4.
Pyle RL, Mitchell JE, Eckert ED, et al. Maintenance treatment and 6-month outcome for bulimic patients who respond to initial treatment. Am J Psychiatry. 1990;147(7):871-5. Call Number: Reason for exclusion: X11. [pmid: 2192562].
Raymond NC, de Zwaan M, Mitchell JE, et al. Effect of a very low calorie diet on the diagnostic category of individuals with binge eating disorder. Int J Eat Disord. 2002;31(1):49-56. Call Number: Reason for exclusion: X7. [pmid: 11835297].
Reeves RS, McPherson RS, Nichaman MZ, et al. Nutrient intake of obese female binge eaters. J Am Diet Assoc. 2001;101(2):209-15. Call Number: Reason for exclusion: X6. [pmid: 11271694].
Rissanen A, Naukkarinen H, Virkkunen M, et al. Fluoxetine normalizes increased cardiac vagal tone in bulimia nervosa. J Clin Psychopharmacol. 1998;18(1):26-32. Call Number: Reason for exclusion: X1. [pmid: 9472839].
Rivera-Nieves J, Kozaiwa K, Parrish CR, et al. Marked transaminase elevation in anorexia nervosa. Dig Dis Sci. 2000;45(10):1959-63. Call Number: Reason for exclusion: X1. [pmid: 11117567].
Rollins N, Piazza E. Anorexia nervosa: A quantitative approach to follow-up. J Am Acad Child Psychiatry. 1981;20(1):167-83. Call Number: Reason for exclusion: X6. [pmid: 7217549].
Rossiter EM, Agras WS, McCann U, et al. Are antidepressants appetite suppressants in bulimia nervosa?. European Journal of Psychiatry. 1991;5(4):224-31. Call Number: Reason for exclusion: X1.
Rossiter EM, Agras WS, Telch CF, et al. Cluster B personality disorder characteristics predict outcome in the treatment of bulimia nervosa. Int J Eat Disord. 1993;13(4):349-57. Call Number: Reason for exclusion: X7. [pmid: 8490637].
Rothschild R, Quitkin HM, Quitkin FM, et al. A double-blind placebo-controlled comparison of phenelzine and imipramine in the treatment of bulimia in atypical depressives. Int J Eat Disord. 1994;15(1):1-9. Call Number: Reason for exclusion: X1. [pmid: 8124322].
Ruggiero GM, Mauri MC, Omboni AC, et al. Nutritional management of anorexic patients with and without fluoxetine: 1-year follow-up. Prog Neuropsychopharmacol Biol Psychiatry. 2003;27(3):425-30. Call Number: Reason for exclusion: X6. [pmid: 12691777].
Russell GF. Premenarchal anorexia nervosa and its sequelae. J Psychiatr Res. 1985;19(23):363-9. Call Number: Reason for exclusion: X6. [pmid: 4045750].
Russell GF, Checkley SA, Feldman J, et al. A controlled trial of d-fenfluramine in bulimia nervosa. Clin Neuropharmacol. 1988;11(Suppl 1):S146-59. Call Number: Reason for exclusion: X7. [pmid: 3052813].
Russell G, Dare C, Eisler I, et al. Controlled trials of family treatments in anorexia nervosa. Halmi KAed. 1992;237:261. Call Number: Reason for exclusion: X3.
Russell JD, Mira M, Allen BJ, et al. Effect of refeeding and exercise in restoration of body protein in anorexia nervosa. Basic Life Sci. 1993;60:207-10. Call Number: Reason for exclusion: X6. [pmid: 8110111].
Rytomaa I, Jarvinen V, Kanerva R, et al. Bulimia and tooth erosion. Acta Odontol Scand. 1998;56(1):36-40. Call Number: Reason for exclusion: X1. [pmid: 9537733].
Rístam M. Anorexia nervosa in 51 Swedish adolescents: premorbid problems and comorbidity. J Am Acad Child Adolesc Psychiatry. 1992;31(5):819-29. Call Number: Reason for exclusion: X12. [pmid: 1400112].
Rístam M, Gillberg C, Garton M. Anorexia nervosa in a Swedish urban region. A population-based study. Br J Psychiatry. 1989;155:642-6. Call Number: Reason for exclusion: X12. [pmid: 2611593].
Sabine EJ, Yonace A, Farrington AJ, et al. Bulimia nervosa: a placebo controlled double-blind therapeutic trial of mianserin. Br J Clin Pharmacol. 1983;15(Suppl 2):195S-202S. Call Number: Reason for exclusion: X11. [pmid: 6337607]. [pmcid: 1427898].
Safer DL, Lively TJ, Telch CF, et al. Predictors of relapse following successful dialectical behavior therapy for binge eating disorder. Int J Eat Disord. 2002;32(2):155-63. Call Number: Reason for exclusion: X2. [pmid: 12210657].
Santonastaso P, Friederici S, Favaro A. Full and partial syndromes in eating disorders: A 1-year prospective study of risk factors among female students. Psychopathology. 1999;32(1):50-6. Call Number: Reason for exclusion: X6. [pmid: 9885401].
Santonastaso P, Friederici S, Favaro A. Sertraline in the treatment of restricting anorexia nervosa: an open controlled trial. J Child Adolesc Psychopharmacol. 2001;11(2):143-50. Call Number: Reason for exclusion: X6. [pmid: 11436953].
Schmidt U, Cooper PJ, Essers H, et al. Fluvoxamine and graded psychotherapy in the treatment of bulimia nervosa: A randomized, double-blind, placebo-controlled, multicenter study of short-term and long-term pharmacotherapy combined with a stepped care approach to psychotherapy. J Clin Psychopharmacol. 2004;24(5):549-52. Call Number: Reason for exclusion: X3.
Schulze U, Neudorfl A, Krill A, et al. [Follow-up and treatment outcome of early anorexia nervosa]. Z Kinder Jugendpsychiatr Psychother. 1997;25(1):5-16. Call Number: Reason for exclusion: X6. [pmid: 9459691].
Scrimali T, Grimali L, Corriere A, et al. [Fluoxetine in the pharmacological treatment of bulimia nervosa]. Rivista Di Psichiatria. 1994;29(3):171-7. Call Number: Reason for exclusion: X15.
Serafinowicz E, Wasikowa R, Iwanicka Z, et al. [Bone metabolism in adolescent girls with short course of anorexia nervosa]. Endokrynol Diabetol Chor Przemiany Materii Wieku Rozw. 2003;9(2):67-71. Call Number: Reason for exclusion: X1. [pmid: 14575614].
Serfaty MA, Turkington D, Heap M, et al. Cognitive therapy versus dietary counselling in the outpatient treatment of anorexia nervosa: Effects of the treatment phase. Eur Eat Disord Rev. 1999;7(5):334-50. Call Number: Reason for exclusion: X2.
Sharp CW, Clark SA, Dunan JR, et al. Clinical presentation of anorexia nervosa in males: 24 new cases. Int J Eat Disord. 1994;15(2):125-34. Call Number: Reason for exclusion: X6. [pmid: 8173558].
Smith DE, Marcus MD, Kaye W. Cognitive-behavioral treatment of obese binge eaters. Int J Eat Disord. 1992;12:257-62. Call Number: Reason for exclusion: X1.
Soomro GM, Crisp AH, Lynch D, et al. Anorexia nervosa in ‘non-white’ populations. Br J Psychiatry. 1995;167(3):385-9. Call Number: Reason for exclusion: X12. [pmid: 7496649].
Steiger H, Stotland S. Prospective study of outcome in bulimics as a function of Axis-II comorbidity: long-term responses on eating and psychiatric symptoms. Int J Eat Disord. 1996;20(2):149-61. Call Number: Reason for exclusion: X1. [pmid: 8863067].
Steinhausen HC, Boyadjieva S, Griogoroiu-Serbanescu M, et al. The outcome of adolescent eating disorders: findings from an international collaborative study. Eur Child Adolesc Psychiatry. 2003;12(Suppl 1):I91-8. Call Number: Reason for exclusion: X4. [pmid: 12567220].
Steinhausen HC, Seidel R. [The Berlin follow-up study of eating disorders in adolescence. Part 2: Intermediate-term catamnesis after 4 years]. Nervenarzt. 1994;65(1):26-34. Call Number: Reason for exclusion: X1. [pmid: 8145873].
Steinhausen HC, Seidel R. [The Berlin follow-up study of eating disorders in adolescence. Part 3: Evaluation and prognosis]. Nervenarzt. 1994;65(1):35-40. Call Number: Reason for exclusion: X1. [pmid: 8145874].
Steinhausen HC, Seidel R, Vollrath M. [Berlin follow-up study of eating disorders in adolescence. I. Inpatient follow-up]. Nervenarzt. 1993;64(1):45-52. Call Number: Reason for exclusion: X1. [pmid: 8437647].
Strasser TJ, Pike KM, Walsh BT. The impact of prior substance abuse on treatment outcome for bulimia nervosa. Addict Behav. 1992;17(4):387-95. Call Number: Reason for exclusion: X6. [pmid: 1502972].
Striegel-Moore RH, Wilfley DE, Pike KM, et al. Recurrent binge eating in black American women. Arch Fam Med. 2000;9(1):83-7. Call Number: Reason for exclusion: X12. [pmid: 10664648].
Strober M, Freeman R, DeAntonio M, et al. Does adjunctive fluoxetine influence the post-hospital course of restrictor-type anorexia nervosa? A 24-month prospective, longitudinal followup and comparison with historical controls. Psychopharmacol Bull. 1997;33(3):425-31. Call Number: Reason for exclusion: X1. [pmid: 9550888].
Strober M, Freeman R, Morrell W. Atypical anorexia nervosa: separation from typical cases in course and outcome in a long-term prospective study. Int J Eat Disord. 1999;25(2):135-42. Call Number: Reason for exclusion: X1. [pmid: 10065390].
Swenne I, Thurfjell B. Clinical onset and diagnosis of eating disorders in premenarcheal girls is preceded by inadequate weight gain and growth retardation. Acta Paediatr. 2003;92(10):1133-7. Call Number: Reason for exclusion: X6. [pmid: 14632326].
Szmukler GI, Brown SW, Parsons V, et al. Premature loss of bone in chronic anorexia nervosa. Br Med J (Clin Res Ed). 1985;290(6461):26-7. Call Number: Reason for exclusion: X6.
Telch CF, Agras WS. The effects of a very low calorie diet on binge eating. Behavior Therapy. 1993;24:177-93. Call Number: Reason for exclusion: X4.
Telch CF, Agras WS, Rossiter EM, et al. Group cognitive-behavioral treatment for the nonpurging bulimic: an initial evaluation. J Consult Clin Psychol. 1990;58(5):629-35. Call Number: Reason for exclusion: X4. [pmid: 2254511].
Theander S. Outcome and prognosis in anorexia nervosa and bulimia: some results of previous investigations, compared with those of a Swedish long-term study. J Psychiatr Res. 1985;19(23):493-508. Call Number: Reason for exclusion: X8. [pmid: 3862842].
Thiels C, Schmidt U, Treasure J, et al. Four-year follow-up of guided self-change for bulimia nervosa. Eat Weight Disord. 2003;8(3):212-7. Call Number: Reason for exclusion: X1. [pmid: 14649785].
Thiels C, Schmidt U, Treasure J, et al. [How effective and acceptable is a self-treatment manual with concomitant brief therapy in bulimia nervosa]. Nervenarzt. 1998;69(5):427-36. Call Number: Reason for exclusion: X6. [pmid: 9629559].
Toner BB, Garfinkel PE, Garner DM. Affective and anxiety disorders in the long-term follow-up of anorexia nervosa. Int J Psychiatry Med. 1988;18(4):357-64. Call Number: Reason for exclusion: X1. [pmid: 3235281].
Toner BB, Garfinkel PE, Garner DM. Long-term follow-up of anorexia nervosa. Psychosom Med. 1986;48(7):520-9. Call Number: Reason for exclusion: X1. [pmid: 3763791].
Treasure J, Schmidt U, Troop N, et al. First step in managing bulimia nervosa: controlled trial of therapeutic manual. BMJ. 1994;308(6930):686-9. Call Number: Reason for exclusion: X13. [pmid: 8142791]. [pmcid: 2539358].
Treasure JL, Russell GF, Fogelman I, et al. Reversible bone loss in anorexia nervosa. Br Med J (Clin Res Ed). 1987;295(6596):474-5. Call Number: Reason for exclusion: X1.
Tseng MC, Lee MB, Lee YJ, et al. Long-term outcome of bulimia nervosa in Taiwanese. J Formos Med Assoc. 2004;103(9):701-6. Call Number: Reason for exclusion: X1. [pmid: 15361943].
van der Ham T, van Strien DC, van Engeland H. Personality characteristics predict outcome of eating disorders in adolescents: a 4-year prospective study. Eur Child Adolesc Psychiatry. 1998;7(2):79-84. Call Number: Reason for exclusion: X6. [pmid: 9712374].
Vandereycken W, Pierloot R. Pimozide combined with behavior therapy in the short-term treatment of anorexia nervosa. A double-blind placebo-controlled cross-over study. Acta Psychiatr Scand. 1982;66(6):445-50. Call Number: Reason for exclusion: X8. [pmid: 6758492].
von Wietersheim J, Malewski P, Jäger B, et al. [The effects of psychodynamic inpatient treatments on personality data of patients with anorexia nervosa and bulimia nervosa - results of the German multicenter study (TR-EAT)]. Z Psychosom Med Psychother. 2001;47(4):366-79. Call Number: Reason for exclusion: X7. [pmid: 11731989].
Wadden TA, Bartlett S.J. Very low calorie diets: an overview and appraisal. Treatment of the Seriously Obese Patients. Eds. Wadden, T.A. and VanItallie, T.B. 1992;44–79. Call Number: Reason for exclusion: X6
Waller G. Drop-out and failure to engage in individual outpatient cognitive behavior therapy for bulimic disorders. Int J Eat Disord. 1997;22(1):35-41. Call Number: Reason for exclusion: X6. [pmid: 9140733].
Walsh BT, Agras WS, Devlin MJ, et al. Fluoxetine for bulimia nervosa following poor response to psychotherapy. Am J Psychiatry. 2000;157(8):1332-4. Call Number: Reason for exclusion: X6. [pmid: 10910801].
Walsh BT, Gladis M, Roose SP, et al. A controlled trial of phenelzine in bulimia. Psychopharmacol Bull. 1987;23(1):49-51. Call Number: Reason for exclusion: X11. [pmid: 3299445].
Walsh BT, Gladis M, Roose SP, et al. Phenelzine vs placebo in 50 patients with bulimia. Arch Gen Psychiatry. 1988;45(5):471-5. Call Number: Reason for exclusion: X11. [pmid: 3282482].
Walsh BT, Hadigan CM, Wong LM. Increased pulse and blood pressure associated with desipramine treatment of bulimia nervosa. J Clin Psychopharmacol. 1992;12(3):163-8. Call Number: Reason for exclusion: X1. [pmid: 1629381].
Walsh BT, Stewart JW, Roose SP, et al. A double-blind trial of phenelzine in bulimia. J Psychiatr Res. 1985;19(23):485-9. Call Number: Reason for exclusion: X11. [pmid: 3900362].
Walsh BT, Stewart JW, Roose SP, et al. Treatment of bulimia with phenelzine. A double-blind, placebo-controlled study. Arch Gen Psychiatry. 1984;41(11):1105-9. Call Number: Reason for exclusion: X11. [pmid: 6388524].
Ward A, Campbell IC, Brown N, et al. Anorexia nervosa subtypes: differences in recovery. J Nerv Ment Dis. 2003;191(3):197-201. Call Number: Reason for exclusion: X1. [pmid: 12637848].
Wermuth BM, Davis KL, Hollister LE, et al. Phenytoin treatment of the binge-eating syndrome. Am J Psychiatry. 1977;134(11):1249-53. Call Number: Reason for exclusion: X9. [pmid: 333952].
Wheadon DE, Rampey AH Jr, Thompson VL, et al. Lack of association between fluoxetine and suicidality in bulimia nervosa. J Clin Psychiatry. 1992;53(7):235-41. Call Number: Reason for exclusion: X12. [pmid: 1639742].
Willi J, Giacometti G, Limacher B. Update on the epidemiology of anorexia nervosa in a defined region of Switzerland. Am J Psychiatry. 1990;147(11):1514-7. Call Number: Reason for exclusion: X6. [pmid: 2221165].
Wilson GT, Eldredge KL, Smith D, et al. Cognitive-behavioral treatment with and without response prevention for bulimia. Behav Res Ther. 1991;29(6):575-83. Call Number: Reason for exclusion: X1. [pmid: 1759956].
Wilson GT, Rossiter E, Kleifield EI, et al. Cognitive-behavioral treatment of bulimia nervosa: a controlled evaluation. Behav Res Ther. 1986;24(3):277-88. Call Number: Reason for exclusion: X1. [pmid: 3460591].
Wisniewski L, Epstein LH, Marcus MD, et al. Differences in salivary habituation to palatable foods in bulimia nervosa patients and controls. Psychosom Med. 1997;59(4):427-33. Call Number: Reason for exclusion: X7. [pmid: 9251163].
Witcher DB, Williamson DA. Duration of bulimia nervosa and symptom progression: a retrospective analysis of treatment-seeking bulimics. J Subst Abuse. 1992;4(3):255-61. Call Number: Reason for exclusion: X6. [pmid: 1458043].
Wolf EM, Crowther JH. An evaluation of behavioral and cognitive-behavioral group interventions for the treatment of bulimia nervosa in women. Int J Eat Disord. 1992;11(1):3-15. Call Number: Reason for exclusion: X11.
Wong JC, Lewindon P, Mortimer R, et al. Bone mineral density in adolescent females with recently diagnosed anorexia nervosa. Int J Eat Disord. 2001;29(1):11-6. Call Number: Reason for exclusion: X6. [pmid: 11135327].
Wong S, Au B, Lau E, et al. Osteoporosis in Chinese patients with anorexia nervosa. Int J Eat Disord. 2004;36(1):104-8. Call Number: Reason for exclusion: X1. [pmid: 15185279].
Wood A. Pharmacotherapy of bulimia nervosa--experience with fluoxetine. Int Clin Psychopharmacol. 1993;8(4):295-9. Call Number: Reason for exclusion: X3. [pmid: 8277150].
Yanovski SZ, Gormally JF, Leser MS, et al. Binge eating disorder affects outcome of comprehensive very-low-calorie diet treatment. Obes Res. 1994;2(3):205-12. Call Number: Reason for exclusion: X4. [pmid: 16353422].
Yanovski SZ, Sebring NG. Recorded food intake of obese women with binge eating disorder before and after weight loss. Int J Eat Disord. 1994;15(2):135-50. Call Number: Reason for exclusion: X2. [pmid: 8173559].
Zipfel S, Seibel MJ, Löwe B, et al. Osteoporosis in eating disorders: a follow-up study of patients with anorexia and bulimia nervosa. J Clin Endocrinol Metab. 2001;86(11):5227-33. Call Number: Reason for exclusion: X1. [pmid: 11701682].
Zuercher JN, Cumella EJ, Woods BK, et al. Efficacy of voluntary nasogastric tube feeding in female inpatients with anorexia nervosa. JPEN J Parenter Enteral Nutr. 2003;27(4):268-76. Call Number: Reason for exclusion: X2. [pmid: 12903890].