# Appendix C. Evidence Tables

## Acronyms, Abbreviations, and Definitions

AA: African American

ABW: percentage of avg body wt (matched for age, gender, and height)

ADDM: adjustment disorder with depressed mood

ads: advertisements

aka: also known as

am: morning

AN: anorexia nervosa

ANBP: anorexia nervosa with binge eating and/or purging

ANCOVA: analysis of covariance

ANSS: anorexia nervosa symptom score

ANOVA: analysis of variance

ANR: restricting anorexia nervosa

AN-RDC: anorexia nervosa with concomitant major depression according to RDC

ANSS: Anorexia Nervosa Symptom Score

ASD: Autism spectrum disorder

avg: average

B-ERP: exposure with response prevention to pre-binge cues

BAI: Beck Anxiety Inventory

BAT: Body Attitudes Test

BP: blood pressure

BCE: bone collagen equivalents

BD: body dissatisfaction

BDI: Beck Depression Inventory

BE: binge eating episode

BEAQ: Binge Eating Adjective Checklist

BED: binge eating disorder

BES: Binge Eating Scale

BF: body fat

BFST: Behavioral family systems therapy

BIAQ: Body Image Avoidance Questionnaire

b.i.d.: twice a day

BITE: Bulimic Investigation Test Edinburgh

BMI: body mass index, measured in kg/m^2^

BN: bulimia nervosa

BPD: borderline personality disorder

BSI: Brief Symptom Inventory

BSQ: Body Shape Questionnaire

BSS: Body Satisfaction Scale

BT: Behavioral therapy

CA: California

CAT: cognitive analytical therapy

CFT: conjoint family therapy

CBCL: Child Behavior Checklist

CBT: Cognitive-behavioral therapy

CBT-E: Cognitive-behavioral therapy with exposure

CBT-C: Cognitive-behavioral therapy with cognitive interventions for treatment of body disturbance

CCEI: Crown Crisp Experimental Index

CDI: Children's Depression Inventory

CDRS: Contour Drawing Rating Scale

CFT: conjoint family therapy

CGI: Clinical Global Impression

CGI-S score: Clinical Global Impressions-Severity of Illness scores: 1 = normal, 2 = borderline, 3 = mildly ill, 4 = moderately ill, 5 = markedly ill, 6 = severely ill, 7 = among the most extremely ill.

Chi-square: χ^2^

CI: confidence interval

cm: centimeter

CNT: cognitive nutritional therapy

Co: company

CR: clinician rating

CT: Connecticut

CT: cognitive therapy

CUE: physiological cue assessment

d: day

DBT: Dialectical Behavior Therapy

DIET: Dieter's Inventory of Eating Temptations Questionnaire

Diff: Diff/Different

DSM IV: Diagnostic and Statistical Manual for Mental Disorders, Fourth Edition

DSM III: Diagnostic and Statistical Manual for Mental Disorders, Third Edition

DSM III-R: Diagnostic and Statistical Manual for Mental Disorders, Third Edition, Revised

DT: drive for thinness

Dx: diagnosis

EAT: Eating Attitudes Test

EB-IV: Diagnostic and Statistical Manual for Mental Disorders, eating behavior IV

EBT: educational behavioral therapy

ECG: electrocardiogram

ECT: Experimental Cognitive Therapy

ED: eating disorder

EDE: Eating Disorders Examination

EDE-Q: Eating Disorders Examination-Questionnaire

EDI: Eating Disorder Inventory

EDNOS: Eating disorder-not otherwise specified

EE: expressed emotion

EOIT: ego oriented individual therapy

ERP: exposure with response prevention

ES: effect size

et al: et alia

EWL: excess weightt loss

EXRP: exposure with response prevention

F: F-statistic

FAM-III: Family Assessment Measure

FBNCSG: Fluoxetine bulima nervosa collaborative study group

FH: family history

FL: Florida

FNE: Fear of Negative Evaluation

FRS: Figure Rating Scale

FU: FU

fx: function

g: grams

G: group

GAF: Global Assessment of Functioning Scale

GAF-S: Global Assessment of Functioning-Symptoms

GAF-F: Global Assessment of Functioning-Functionging

GCBT: group cognitive behavioral therapy

GEE: Generalized estimating equation

GI: gastrointestinal

GP: general practitioner

GSI: General Severity Index

HAM-A: Hamilton Rating Score for Anxiety

HAM-D: Hamilton Rating Score for Depression

HBT: Hypnobehavioral therapy

HDRS: Hamilton Depression Rating Scale (also HRSD: Hamilton Rating Scale for Depression)

HM: hazard multiplier

HRQ: Helping Relationship Questionnaire

HS: High School

HSCL: Hopkins Symptom Checklist

hr: hours

ht: height

Hx: history

IBC: Interaction Behavior Code

IBW: ideal body weight

ICBT: individual cognitive behavioral therapy

ICD: International Classification of Diseases

IDDB: Insulin dependent diabetes mellitus

IGF-1:

IL: Illinois

Inc.: Incorporated

info: information

IPT: Interpersonal psychotherapy

ITT: intention to treat

K _2_ HPO _4_ /cm ^3^: measure of bone mineral density (BMD)

kcal: kilocalories

Kg: kilograms

KS: Kansas

l: liter

LAGB: laparoscopic adjustable gastric banding

lb: pounds

LIFE: Longitudinal Interval FU Evaluation

Ltd.: limited

m: minutes

MA: Massachusetts

MADRS: Montgomery-Asberg Depression Rating Scale

MANCOVA: multivariate analysis of covariance

MANOVA: multivariate analysis of variance

MAOI: monoamine-oxidase inhibitors

max: maximum

MD: Maryland

MDD: major depressive disorder

MDE: major depressive episode

meds: medication(s)

MET: Motivational Enhancement therapy

mg: milligram

Mg: micrograms

MI: Michigan

Min: minimum

MKAT: measurement of bone specific alkaline phosphatase

mm Hg: millimeters mercury

MMPI: Minnesota Multiphasic Personality Inventory

MMPW: mean matched population wt

mmol: millimole

MN: Minnesota

MOCI: Maudsley Obsessive Compulsive Inventory

mo: month(s)

M-R Scores: Morgan and Russell scale

M-R-H Scale: Morgan-Russell-Hayward Scale

N: number

NA: not applicable

NATO: North Atlantic Treaty Organization

NBPD: non-borderline personality disorder

neg: negative

NG: nutritional groups

NIH: National Institutes of health

NIMH: National Institute of Mental Health

NJ: New Jersey

nM: nanomole

N: number

NC: North Carolina

NICHD: National Institute for Child Health and Development

NM: New Mexico

nmol: nanomile

NR: not reported

NS: not significant

NSMT: Non-specific Self Monitoring

NT: nutritional therapy

NY: New York

NYC: New York City

OBE: objective binge episode

OC: obsessive-compulsive

OCD: obsessive-compulsive disorder

OCPD: obsessive-compulsive personality disorder

outpt: outpatient

OR: odds ratio

P: p-value

P61: Patient's gloval impression

PA: Pennsylvania

PARQ: Parent Adolescent Relationship Questionnaire

P-ERP: exposure with response prevention to pre-purge cues

PE: psychoeducation

PGI: Patient Global Impression

PICP: C-terminal propeptide of type 1 collagen

pmol: picomole

po: per os (by mouth)

pos: positive

PSE: Present State Exam

PSR: Psychiatric Status Rating Scale

psych: psychological or psychiatric

PTSD: posttraumatic stress disorder

QEWPR: Questionnaire on Eating and Wt Patterns - Revised

RAN: restricting anorexia nervosa

RCT: randomized controlled trial

RDC: Research Diagnostic Criteria

RELAX: relaxation training

rhGh: recombinant human growth hormone

RI: Rhode Island

RP: response prevention

RM-ANOVA: repeated measures analysis of variance

RSE: Rosenberg Self Esteem Inventory

RSEQ: Rosenberg Self-Esteem Questionnaire

SADS-C: Schedule for Affective Disorders and Schizophrenia-Change Version

SAS: Social Adjustment Scale

SCI: Shapiro Control Inventory

SCID: Structured Clinical Interview for DSM IV

SCL-90: Hopkins Symptom Checklist-90

SD: standard deviation

SDS: Self-rating Depression Scale

SE: standard error

SEM: standara error of the mean

SES: socioeconomic status

SF-36: Short-Form 36-item quality of life questionnaire

- RP: role physical component score
- SF: social functioning component score
- Vit: vitality component score

SFT: Separated family therapy

SIAB: Structured Interview for Anorexia Nervosa and Bulimic Syndromes

Sig: significant

SMFQ: Short Mood and Feeling Questionnaire

SMR: Standardized Mortality Ratio

SOC: stages of change

SPAQ: Seasonal Patterns Assessment Questionnaire

SR: Self-report

SRQ: Three Factor Eating Questionnaire

SRS: Self-Rating Depression Scale

SSRI: selective serotonin reuptake inhibitor

St: Saint

STAI: State/Trait Anxiety Inventory

STAXI: State Trait Anger Expression Inventory

SUD: substance use disorder

SUDS: Subjective units of distress

sx: symptoms

T: time

t.i.d.: three times a day

TAS-20: Toronto Alexithymia Scale

TCA: tricyclic antidepressants

TFEQ: Three Factor Eating Questionnaire

TN: Tennessee

TT _3_: total testosterone

tx: treatment

U: university

UK: United Kingdom

USA: United States

UT: Utah

UTB: Urge to binge

UTP: Urge to purge

VAS: visual analog scale

vs: versus

WAIS: Wechsler Adult Intelligence Scale

WELSQ: Weight Efficacy Life Style Questionnaire

WLFL: Work, Life and Family Leisure Questionnaire

WI: Wisconsin

wk: week

wkly: weekly

WPIC: Western Psychiatric Institute and Clinic

wt: weight

X ^2^: chi square

YBC-ED: Yale-Brown-Cornell Eating Disorders Scale

Y-BOCS: Yale-Brown Obsessive Compulsive Scale

Y-BOCS-BE: Yale-Brown Obsessive Compulsive Scale Modified for Binge Eating

Yr: year

Yrs: years

Evidence Table 1. Medication trials for anorexia nervosa

| | | | | | | | Eating Related Measures | | Psychological/Psychiatric Measures | | Biomarkers
Study Description | Objective | Design | Patient Characteristics | Inclusion/Exclusion Criteria | Treatment | Statistical Methods | Quality | Baseline | Outcomes | Baseline | Outcomes | Baseline | Outcomes
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Inpatient tx: | Paired t tests, ANCOVA, ANOVA | Score: | Anorexic Behavior Scale, mean (SD): | Anorexic Behavior Scale, mean (SD): | CGI, Illness, mean (SD): | CGI, Illness, mean (SD): | Wt, % of IBW, mean (SD): | Wt, % of IBW, mean (SD):
Attia et al., 1998 | To determine whether fluoxetine was associated with greater wt gain and improved psychological functioning compared to placebo when combined with a structured inpatient program for AN. | G1: Fluoxetine (N = 15) | 26.2 (7.4) | Female, between 16–45 yrs old, receiving inpatient tx for AN. Met DSM IV criteria A-C for AN, wt < 80% of IBW. | Seen 3–5 times/wk in individual therapy. Several group sessions. Random assignment occurred after patient was medically stable and after having reached 65% IBW. | | Good | G1: 49.0 (14.3) | G1: 38.5 (11.6) (P < 0.05) | G1: 5.3 (1.0) | G1: 4.1 (1.4) (P < 0.05) | G1: 73.3 (5.8) | G1: 86.6 (6.3) (P < 0.05)
Setting: | | G2: Placebo (N = 16) | G1: 29.1 (7.2) | Exclusion: | G1: initiated at 20 mg/day and increased to 60 mg /day over 1 wk and was maintained unless side effects occurred. | | Intent to treat: | G2: 43.2 (11.2) | G2: 39.7 (9.5) (P = NS) | G2: 5.3 (1.2) | G2: 4.3 (1.5) (P < 0.05) | G2: 71.8 (5.0) | G2: 87.4 (4.7) (P < 0.05)
Inpatient research unit, NY, USA | | Enrollment: | G2: 23.4 (6.4) | Medically unstable, allergy to fluoxetine, alcohol or drug dependence in past 6 mo, bipolar disorder or psychotic disorder (current or lifetime), OCD with onset before AN. | Patients continued with study until reached 90% IBW and remained at or above for 1 wk or for a max of 7 wks. | | No | | Diff between groups (P = NR) | | Diff between groups (P = NR) | | Diff between groups (P = NR)
Enrollment period: | | - 33 enrolled; - 1 drop out; - 1 undetectable levels of meds; - 1 unreliable self- reporter; - 31 included in analyses | (P < 0.03) | | Days of medical tx, mean (SD): | | Blinding: | | Diff between groups in changeover time (P = NS) over time (P = NS) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
NR | | | Sex: | | G1: 36.1 (14.1) | | Double | | | | | | Change in % of IBW, mean (SD):
| | | Female:100% | | G2: 37.4 (13.8) | | Adverse events: | | | | | | G1: 0.35 (0.17) (P = NS)
| | | Race/ethnicity: | | (P = NS) | | Meds related insomnia and agitation in 1 patient and blurred vision in a second. | | | | | | G2: 0.42 (0.11) (P = NS)
| | | NR | | Dose at termination mg/day, mean (SD): | | Funding: | | | | | | Diff between groups (P = NR)
| | | Duration (yrs) of AN, mean (SD): | | G1: 56.0 (11.2) | | Eli Lilly and Co | | | | | | Diff between groups in change over time (P = NS)
| | | 8.0 (5.8) | | G2: 58.7 (5.0) | | | EAT, mean (SD): | EAT, mean (SD): | BDI mean (SD): | BDI mean (SD):
| | | G1: NR | | (P = NS) | | | G1: 53.8 (23.3) | G1: 37.1 (20.1) (P < 0.05) | G1: 24.3 (11.9) | G1: 15.9 (11.3) (P < 0.05)
| | | G2: NR | | | | | G2: 54.1 (19.5) | G2: 30.8 (17.5) (P < 0.05) | G2: 20.0 (7.2) | G2: 14.0 (8.9) (P < 0.05)
| | | (P = NS) | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | Wt, lb, mean (SD): | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | 92.0 (9.8) | | | | | CGI, ED, mean (SD): | CGI, ED, mean (SD): | | CGI, Global Improvement, mean (SD):
| | | G1: NR | | | | | G1: 5.7 (1.0) | G1:4.2 (1.4) (P < 0.05) | | G1: 2.5 (1.4) (P = NS)
| | | G2: NR | | | | | G2: 5.8 (1.0) | G2: 4.1 (1.1) (P < 0.05) | | G2: 2.8 (1.5) (P = NS)
| | | (P = NS) | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | % of IBW, mean (SD): | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | 72.5 (5.3) | | | | | Yale Brown Cornell ED Scale, Preoccupation, mean (SD): | Yale Brown Cornell ED Scale, Preoccupation, mean (SD): | BSQ mean (SD): | BSQ mean (SD):
| | | G1: NR | | | | | G1: 11.1 (3.4) | G1: 8.1 (3.4) (P < 0.05) | G1: 129.9 (48.8) | G1: 109.3 (39.5) (P < 0.05)
| | | G2: NR | | | | | G2: 9.7 (2.3) | G2: 8.1 (2.3) (P < 0.05) | G2: 138.6 (35.1) | G2: 119.4 (31.5) (P = NS)
| | | (P = NS) | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | BMI, mean (SD): | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | 15.0 (4.2) | | | | | Yale Brown Cornell ED Scale, Ritual, mean (SD): | Yale Brown Cornell ED Scale, Ritual, mean (SD): | SCL-90, Depression, mean (SD): | SCL-90, Depression, mean (SD):
| | | G1: NR | | | | | G1: 9.9 (2.6) | G1: 7.7 (2.9) (P < 0.05) | G1: 3.2 (0.9) | G1: 2.3 (1.0) (P < 0.05)
| | | G2: NR | | | | | G2: 9.0 (2.7) | G2: 6.7 (2.6) (P < 0.05) | G2: 2.8 (0.6) | G2: 2.2 (0.8) (P < 0.05)
| | | (P = NS) | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | | Yale Brown Cornell ED Scale, total, mean (SD): | Yale Brown Cornell ED Scale, total, mean (SD): | SCL-90, OC scale, mean (SD): | SCL-90, OC scale, mean (SD):
| | | | | | | | G1: 20.9 (5.7) | G1: 15.7 (6.1) (P < 0.05) | G1: 2.5 (1.0) | G1: 1.9 (1.0) (P < 0.05)
| | | | | | | | G2: 18.7 (4.3) | G2: 14.8 (4.2) (P < 0.05) | G2: 2.3 (0.9) | G2: 1.7 (0.5) (P < 0.05)
| | | | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | | | | SCL-90, Global symptom, mean (SD): | SCL-90, Global symptom, mean (SD):
| | | | | | | | | | G1: 2.4 (0.7) | G1: 1.9 (0.8) (P < 0.05)
| | | | | | | | | | G2: 2.3 (0.6) | G2: 1.8 (0.5) (P < 0.05)
| | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Tx lasted 6 mos. All enrolled subjects started on a dose of 20 to 40 mg of fluoxetine. Individual doses titrated throughout study. Dose at study end ranged from 20 to 60 mg. Subjects wted at wkly intervals for the first 8 wks, at 2-wk intervals for 6 wks, and at 4 wk intervals for 12 wks. | Independent sample t-tests for measuring changes between groups. | Score: | NR | NR | | Estimate is change over time (SE) | | Estimate is change over time (SE)
Barbarich, McConaha et al. 2004 | To determine if the use of supplements containing tryptophan and essential fatty acids would increase the efficacy of flouxetine in underwt AN subjects. | G1: daily dietary supplements (N = 15) | Mean: 23.0 (6.3) yrs | NR | In addition, G1 received 2.3 g tryptophan taken in divided dosage in the am and pm, 1 multivitamin/mineral capsule per day in the am, and 4 fish oil capsules per day in the am (600 mg of docosahexanoic acid and 180 mg of arachadonic acid). G2 received equivalent number of inactive capsules | | Poor | | | STAI-Y: | STAI - Y: | NR | Mean wt gain per wk:
Setting: | | G2: Placebo (N = 11) | G1: NR | Exclusion: | | | Intent to treat: | | | G1: 43.5 (17.6) | G1: -7.8 (23.8) | | G1: 0.27 kg (0.3)
Eating Disorders programs at WPIC, Pittsburgh, PA and NY Hospital/Cornell Medical Center, NYC, USA. | | Enrollment: | G2: NR | NR | | | No | | | G2: 54.5 (3.5) | G2: -10.5 (0.7) | | G2: 0.10 kg (0.1)
Enrollment period: | | - 26 enrolled and randomized; - 9 completed full study | (P = NR) | | | | Blinding: | | | (P = NS) | Diff between groups (P = NR) | | Diff between groups (P = NR)
NR | | | Sex: | | | | Double | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | Female: NR | | | | Adverse /events: | | | YBOCS: | YBOCS:
| | | Race/ethnicity: | | | | NR | | | G1: 11.8 (14.2) | G1: -9.2 (12.9)
| | | NR | | | | Funding: | | | G2: 12.0 (11.3) | G2: -6.5 (3.5)
| | | Other characteristics: | | | | NR | | | (P = NS) | Diff between groups (P = NR)
| | | AN restricting type (N = 10) | | | | | | | | Diff between groups in change over time (P = NS)
| | | AN restricting and purging only (N = 6)
| | | AN Binge eating/purging type (N = 10)
| | | Characteristics for completers only:
| | | No sig diff between completers and drop outs on any measures except mean laxative abuse onset age (SD):
| | | Noncompleters: 16.3 (1.6)
| | | Completers: 21.3 (1.2);
| | | Diff between groups
| | | (P < 0.01)
| | | Measures, mean (SD):
| | | - Dieting start age: 16.9 (5.2); - Age of onset: 17.3 (6.3); - Duration of ED: 8.4 (8.1); - Binge eating start: 17.8 (6.9); - Laxative abuse start: 21.3 (1.2); - Vomiting start age: 20.2 (6.9); - Age: 25.7 (7.4); - Low BMI: 14.4 (1.4); - High BMI: 20.8 (2.3); - Perfectionism score (Frost multidimensional perfectionism scale): 87.8 (28.4)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | All received regular psychiatric and medical tx (supportive, nutritional rehab illitation, individual therapy, family intervention, and inpatients received behavior modification). Meds: dosage increased every other day by 50 mg up to 3 mg/kg/day and a max dose of 175 mg/day unless adverse effects developed. Mean dose at wk 5: 115 (31) mg/day; 2.8 (1.1 mg/kg/day). Plasma levels varied among patients on the same dose of meds. | T-tests to compare placebo and drug group Diffs. One-way ANOVA to determine whether diffs emerged in change scores across groups. Correlations between improvement and plasma levels of meds. | Score: | | Antibulimic effect (EAT-Bulimic factor): | Family Hx (FH): | Antidepressant effect | Wt kg, mean (SD): | Wt gain:
Biederman et al., 1985 | To investigate effect of amitriptyline on wt and psychiatric sx's in AN. | G1: Amitriptyline (N = 11) | G1: 18.4 (4.9) | Dx for AN per Feighner et al. (1972) and DSM III. All but 1 patient met full criteria. | | | Fair | | < 30% response, N (%): | Depression (1st degree), N (%): | (SADS-C): | G1: 38.2 (4.2) | < 10%, N (%):
Setting: | | G2: Placebo (N = 14) | G2: 17.2 (4.3) | Exclusion: | | | Intent to treat: | | G1: 2 (22%) | G1: 6 (54%) | < 30% response, N (%): | G2: 35.5 (5.8) | G1: 8 (72%)
Inpatient Eating Disorder Unit, Massachusetts General Hospital; Psychosomatic Unit, Children's Hospital Medical Center, Boston, USA | | Enrollment: | Range: 11–27 | Evidence of other medical disorders | | | No | | G2: 8 (57%) | G2: 6 (43%) | G1: 8 (73%) | (P = NS) | G2: 8 (57%)
Enrollment period: | | - 25 patients enrolled; - 5 outpatients and 11 inpatients | (P = NS) | | | | Blinding: | | 30 to 50% response, N (%): | AN-RDC (AN with concomitant depression), N (%): | G2: 6 (46%) | Percent below ideal (wt for ht at baseline), mean (SD): | 10 to 30%, N (%):
Dates NR (2 yrs) | | | Sex: | | | | Double | | G1: 1 (11%) | G1: 4 (36%) | 30 to 50% response, N (%): | G1: 25.0 (7.3) | G1: 3 (27%)
| | | Female: NR | | | | Adverse events: | | G2: 1 (7%) | G2: 10 (71%) | G1: 3 (27%) | G2: 31.0 (6.2) | G2: 5 (36%)
| | | Race/ethnicity: | | | | Assessed wkly. | | >50% response, N (%): | (P = NS) | G2: 5 (36%) | (P = NS) | > 50%, N (%):
| | | NR | | | | G1: diaphoresis (N = 2; 18%), drowsiness (N = 6, 55%), dry mouth (N = 4; 36%), blurred vision (N = 1; 9%), urinary retention (N = 1; 9%), hypotension (N = 2; 18%), leucopenia (N = 1; 9%) | | G1: 6 (67%) | Generation-FH (depression or substance abuse in 2 or more consecutive generations) N (%): | >50% response, N (%): | | G1: 0 (0%)
| | | SES (range 1–5), mean (SD): | | | | G2: Dry mouth (N = 2; 14%), palpitations (N = 1; 7%), dizziness (N = 2; 14%). No P-values reported | | G2: 5 (36%) | G1: 1 (10%) | G1: 0 (0%) | | G2: 1 (7%)
| | | G1: 2.4 (1.2) | | | | Funding: | | (P-values NR; described as NS) | G2: 3 (21%) | G2: 2 (14%) | | (P-values NR; described as NS)
| | | G2: 2.0 (1.4) | | | | NIMH, Charlupski Foundation, Milton Fund, Jane Hilder Harris Foundation. | | | (P = NS) | (P-values NR; described as NS)
| | | (P = NS) | | | | | | | | Antianxiety effect (SADS-C): | | Plasma levels:
| | | Age onset (yrs) of AN, mean (SD): | | | | | | | | < 30% response, N (%): | | No correlation between plasma levels and any outcome variable.
| | | G1: 15.7 (1.2) | | | | | | | | G1: 9 (82%)
| | | G2: 16.1 (2.7) | | | | | | | | G2: 8 (61%)
| | | (P = NS) | | | | | | | | 30 to 50% response, N (%):
| | | Duration (mos) of present episode, mean (SD): | | | | | | | | G1: 2 (18%)
| | | G1: 20.2 (16.7) | | | | | | | | G2: 3 (25%)
| | | G2: 25.2 (29.4) | | | | | | | | >50% response, N (%):
| | | (P = NS) | | | | | | | | G1: 0 (0%)
| | | | | | | | | | | G2: 2 (15%)
| | | | | | | | | | | (P-values NR; described as NS)
| | | | | | | | | | | Antiobsessional effect (HSCL):
| | | | | | | | | | | < 30% response, N (%):
| | | | | | | | | | | G1: 9 (100%)
| | | | | | | | | | | G2: 12 (86%)
| | | | | | | | | | | 30 to 50% response, N (%):
| | | | | | | | | | | G1: 0 (0%)
| | | | | | | | | | | G2: 1 (7%)
| | | | | | | | | | | >50% response, N (%):
| | | | | | | | | | | G1: 0 (0%)
| | | | | | | | | | | G2: 1 (7%)
| | | | | | | | | | | (P-values NR; described as NS)
| | | | | | | | | | | Global effect (Clinical Global; Global Severity Scale):
| | | | | | | | | | | < 30% response, N (%):
| | | | | | | | | | | G1: 6 (54%)
| | | | | | | | | | | G2: 9 (64%)
| | | | | | | | | | | 30 to 50% response, N (%):
| | | | | | | | | | | G1: 4 (36%)
| | | | | | | | | | | G2: 4 (27%)
| | | | | | | | | | | > 50% response, N (%):
| | | | | | | | | | | G1: 1 (9%)
| | | | | | | | | | | G2: 1 (7%)
| | | | | | | | | | | (P-values NR; described as NS)
| | | | | | | | | | Substance use disorder (1st degree), N (%):
| | | | | | | | | | G1: 3 (27%)
| | | | | | | | | | G2: 6 (43%)
| | | | | | | | | | (P = NS)
| | | | | | | | | | TCA used previous to study, N (%):
| | | | | | | | | | G1: 1 (9%)
| | | | | | | | | | G2: 2 (14%)
| | | | | | | | | | (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Routine inpatient tx for AN including group and individual psychotherapy; psychiatric meds and enteral feeding was individualized. On day 7 of admission baseline measures collected. Patient began trial of 14 mg of elemental zinc or placebo on day 8. The study of each patient was terminated when a 10% wt gain above baseline was achieved on 2 consecutive biwkly wtings. | Two-tailed tests. Mann-Whitney U to compare zinc and placebo groups. Chi square with Yates correction used to compare number of patients in each group who received psychiatric meds | Score: | NR | NR | NR | NR | BMI, mean (SD): | Rate BMI gain/day, mean (SD):
Birmingham, Goldner et al., 1994 | To determine whether zinc supplementation of hospitalized AN patients would enhance their rate of recovery as measured by the rate of increase in their BMI. | G1: zinc (N = 26) | G1: 20.6 (3.8) | Female, ≥ 15 yrs old, inpatient for AN tx | | | Fair | | | | | G1: 15.6 (1.2) | G1: 0.079 (0.07) (P = NR)
Setting: | | G2: placebo (N = 28) | G2: 23.8 (6.1) | Exclusion: | | | Intent to treat: | | | | | G2: 16.2 (1.8) | G2: 0.039 (0.06) (P = NR)
Inpatient eating disorders programs; St. Paul's Hospital, Health Sciences Centre Hospital, and the University of British Columbia, Vancouver, British Columbia, Canada. | | Enrollment: | (P = NS) | NR | | | No | | | | | (P = NS) | Diff between groups (P = NR)
Enrollment period: | | - 54 randomized; - 35 patients completed | Sex: | | | | Blinding: | | | | | | Diff between groups in change over time (P = 0.03)
September 1988-June 1991 | | G1: N = 16 | Female: 100% | | | | Double | | | | | | G1 greater than G2
| | G2: N = 19 | Race/ethnicity: | | | | Adverse events: | | | | | % total body fat, mean (SD): | Rate % body fat gain/day, mean (SD):
| | | NR | | | | No adverse events reported | | | | | G1: 15.0 (5.5) | G1: 0.18 (0.18)
| | | Hospitalizations, mean (SD): | | | | Funding: | | | | | G2: 15.0 (4.0) | (P = NR)
| | | G1: 1.9 (1.6) | | | | Vancouver Foundation | | | | | (P = NS) | G2: 0.02 (0.27)
| | | G2: 2.1 (1.8) | | | | | | | | | | (P = NR)
| | | (P = NS) | | | | | | | | | | Diff between groups
| | | Yrs since dx, mean (SD): | | | | | | | | | | (P = NR)
| | | G1: 3.6 (2.0) | | | | | | | | | | Diff between groups in change over time
| | | G2: 3.8 (3.2) | | | | | | | | | | (P = NS)
| | | (P = NS) | | | | | | | | | | Total wt gain (kg), mean (SD):
| | | | | | | | | | | | | G1: 3.6 (2.0) (P = NR)
| | | | | | | | | | | | | G2: 2.6 (2.7) (P = NR)
| | | | | | | | | | | | | Diff between groups
| | | | | | | | | | | | | (P = NS)
| | | | | | | | | | | | | Diff between groups in change over time
| | | | | | | | | | | | | (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD) (range): | Inclusion: | CBT, nutritional counseling, and pharmacotherapy | Student t test and MANCOVA for repeated measures with time by group. | Score: | EDI, Global Score, mean (SD): | EDI, Global Score at 4 mos, mean (SD): | HAM-D, mean (SD): | HAM-D at 4 mos, mean (SD): | BMI, mean (SD): | BMI, mean (SD) at 4 mo:
Brambilla et al., 1995 | To determine if a 4-mo course of combined cognitive-behavioral, nutritional, and antidepressant therapy (amineptine or fluoxetine) results in positive clinical effects in patients with AN-binge-eating/purging subtype. | G1: Fluoxetine (N = 6) | 23.1 (6.8) (17–43) | Dx of AN per DSM III-R and IV criteria | G1: 60 mg/day of fluoxtine orally (P.o.) | | Poor | G1: 99.6 (31.6) | G1: 74.0 (13.7) (P = NR) | G1: 19.7 (7.3) | G1: 11.2 (6.9) (P = NR) | G1: 16.7 (2.2) | G1: 21.1 (6.3) (P = NS)
Setting: | | G2: Amineptine (N = 7) | G1: NR | Exclusion: | G2: 300 mg/day of aminepine (P.o.) | | Intent to treat: | G2: 82.3 (42.7) | G2: 46.2 (16.4) (P = NR) | G2: 20.2 (5.6) | G2: 11.2 (7.8) (P = NR) | G2: 16.3 (2.8) | G2: 17.7 (2.6) (P = NS)
Outpatient, Center for Eating Disorders of the Dipartimento di Scienze Neuropsichiche Universita, Milan, Italy | | Enrollment: | G2: NR | NR | Length of Treatment: | | Yes | (P = NR) | Change over time (P = 0.02) | (P = NR) | Change over time (P = 0.002) | (P = NR) | Diff between groups (P = NR)
Enrollment period: | | N = 13 | Sex: | | 4 mos | | Blinding: | | Diff between groups (P = NR) | | Diff between groups (P = NS) | | Diff between groups in change over time (P = NS)
NR | | Completed: 100%; N = 13 | Female: 100% | | | | NR | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NR)
| | | Race/ethnicity: | | | | Adverse events: | BITE, symptoms mean (SD): | BITE, symptoms at 4 mos, mean (SD): | HAM-A, mean (SD): | HAM-A at 4 mos, mean (SD):
| | | NR | | | | None | G1: 19.7 (4.4) | G1: 23.8 (3.6) (P = NR) | G1: 85.7 (20.9) | G1: 50.4 (34.8) (P = NR)
| | | Length of illness, yrs, mean (SD) (range): 4.6 (3.9) (3 mos - 13 yrs) | | | | Funding: | G2: 20.2 (6.4) | G2: 18.8 (7.7) (P = NR) | G2: 89.4 (11.2) | G2: 37.0 (31.0) (P = NR)
| | | G1: NR | | | | NR | (P = NR) | Change over time (P = NR) | (P = NR) | Change over time (P = 0.001)
| | | G2: NR | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NS)
| | | Amenorrheic, N: | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | 3 | | | | | BITE, gravity mean (SD): | BITE, gravity at 4 mos, mean (SD):
| | | | | | | | G1: 10.7 (6.0) G2: 12.0 (7.7) | G1: 10.4 (4.8) (P = NR)
| | | | | | | | (P = NR) | G2: 12.0 (6.3) (P = NR)
| | | | | | | | | Change over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Binge eating (not defined), mean (SD): | Binge eating, mean (SD):
| | | | | | | | G1: 3.5 (2) | G1: 3.2 (1.8) (P = NS)
| | | | | | | | G2: 4.1 (1) | G2: 4.4 (0.5) (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Vomiting (not defined), mean (SD): | Vomiting, mean (SD):
| | | | | | | | G1: 3.2 (2.3) | G1: 2.2 (1.8) (P = NS)
| | | | | | | | G2: 3.6 (2.3) | G2: 1.8 (2.0) (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | All randomized subjects were part of a waitlist group for entering an integrated, usual practice tx for AN; half of subjects randomized to citalopram group and half to waitlist control group. Over 12 wk tx, subjects in citalopram group initiated on 10 mg/day of the drug and increased to 20 mg/day after 6 days of tx. Subjects in the control group also followed by periodic clinical assessment and the administration of questionnaires of interest. | MANOVAs to assess the efficacy of citalopram versus waitlist control (at baseline and 12 wks); univariate analyses to assess within group diffs on questionnaire measures (at baseline and 12 wks); multiple regression models to assess the effect of citalopram on the outcome variables while controlling for age, duration of disease, personality disorders, and BMI at baseline. | Score: | EDI-2, mean (SD): | EDI-2, mean (SD): | BDI, mean (SD): | BDI, mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD):
Fassino et al., 2002 | To study the efficacy of citalopram (an SSRI) in the outpatient tx of AN restricting type | G1: citalopram (N = 26) | G1: 24.35 (5.38) | Dx of AN restricting type; age 16–35; no psychopharmacologic tx within the mo preceding the beginning of the study or 6 wks without tx with fluoxetine (an exception was made for 4 subjects who were permitted to continue tx with lorazepam for anxiety-related sxs); no estrogen-progesterone therapy for the last mo | | | Poor | Bulimia | Bulimia | G1: 14.46 (7.73) | G1: 7.31 (5.07) | G1: 16.19 (0.81) | G1: 17.47 (1.41)
Setting: | | G2: waitlist control (N = 26) | G2: 25.23 (8.64) | Exclusion: | | | Intent to treat: | G1: 5.88 (6.71) | G1: 2.26 (4.07) | G2: 12.65 (6.39) | G2: 12.30 (9.02) | G2: 15.62 (1.42) | G2: 16.33 (1.68)
Single center; outpatient; Centre for Eating Disorders, Turin University; Turin, Italy | | Enrollment: | (P = NS) | Psychiatric comorbidity; sensitivity to citalopram | | | NR | G2: 3.31 (3.66) | G2: 3.30 (3.67) | (P = NR) | Diff between groups (P = NR) | (P = NR) | Diff between groups (P = NR)
Enrollment period: | | - 98 screened who were consecutively admitted AN patients; - 52 met criteria for AN restricting type and were randomized; - 39 participants (G1 = 19, G2 = 20) remained by wk 12 | Sex: | | | | Blinding: | (P = NR) | Diff between groups (P = NR) | | Change over time from baseline to wk 12: | | Change over time from baseline to 12 wks:
September 1, 1998 through September 1, 2000 | | Open label study, no masking of observers | Female: 100% | | | | None | | Change over time from baseline to wk 12: | | G1: -7.15 (P = 0.001) | | G1: 1.28 (P = 0.002)
| | | Race/ethnicity: | | | | Adverse events: | | G1: 3.62 (P = 0.005) | | G2: -0.35 (P = NS) | | G2: 0.71 (P = 0.005)
| | | NR | | | | NR | | G2: 0.01 (P = NS) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | Age of onset, mean (SD): | | | | Funding: | | Diff between groups in change over time (P = NR)
| | | G1: 18.42 (4.16) | | | | NR | | | SCL-90, mean (SD): | SCL-90, mean (SD): | Wt, kg, mean (SD): | Wt, kg, mean (SD):
| | | G2: 17.69 (3.92) | | | | | | | Depression: | Depression: | G1: 43.48 (3.93) | G1: 46.47 (5.33)
| | | (P = NS) | | | | | | | G1: 26.73 (11.56) | G1: 17.11 (9.39) | G2: 42.48 (4.60) | G2: 43.92 (4.86)
| | | Duration of disease in yrs, mean (SD): | | | | | | | G2: 23.69 (12.49) | G2: 22.55 (12.78) | (P = NR) | Diff between groups (P = NR)
| | | G1: 5.69 (4.90) | | | | | | | (P = NR) | Diff between groups (P = NR) | | Change over time from baseline to 12 wks:
| | | G2: 7.54 (8.19) | | | | | | | | Change over time from baseline to wk 12: | | G1: 2.99 (P = 0.003)
| | | (P = NS) | | | | | | | | G1: - 9.62 (P = 0.001) | | G2: 1.44 (P = 0.007)
| | | Duration of amenorrhea in mos, mean (SD): | | | | | | | | G2: - 1.14 (P = NS) | | Diff between groups in change over time (P = NR)
| | | G1: 15.81 (14.83) | | | | | | | | Diff between groups in change over time (P = NR)
| | | G2: 20.11 (25.35) | | | | | | | Anxiety: | Anxiety:
| | | (P = NS) | | | | | | | G1: 17.38 (8.16) | G1: 12.74 (6.59)
| | | | | | | | | | G2: 15.65 (9.26) | G2: 14.15 (8.78)
| | | | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | | | Change over time from baseline to wk 12:
| | | | | | | | | | | G1: - 4.64 (P = 0.005)
| | | | | | | | | | | G2: - 1.50 (P = 0.054)
| | | | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD) (range): | Inclusion: | Baseline assessment on days 2 and 5 of the 7 day pre-tx period, conducted wkly during tx until patient reached within 5% of a normal wt for age and height (Per Iowa Growth Chart and 1959 Metropolitan Height-Wt Chart). Drug dosage was increased per discretion of the investigator to obtain max drug dosage (cyproheptadine: 32 mg; amitriptyline: 160 mg) at the end of the 2nd wk of tx. Patients maintained on highest tolerated dosage. | Computed “tx efficiency” = reciprocal of days to target wt X 90 (max days of tx). Chi Square, hierarchical multiple regression controlling for hospital, pre-tx wt, drug intervention, and interactions, ANOVA | Score: | Caloric Intake, mean (SD): | Caloric Intake, mean (SD): Treatment wk: | BDI, mean (SD): | BDI, mean (SD): Day 14: | | Treatment efficiency, mean (SD) (N = 72):
Halmi et al., 1986 | To assess the effects of amitriptyline and cyproheptadine for the tx of AN in an inpatient setting. | G1: amitriptyline (N = 23) | 20.56 (5.1) (13 to) | DSM III criteria for AN plus amenorrhea | During the 7 day pre tx: patients could choose their own food. During drug tx, patients received nutritious liquid product (Sustacal) diluted to 1 kcal/mL given in 6 equal feedings which was the only source of nutrients for first 15 days of tx (allowed as much as they wanted). After 15 days, patients received 3 meals of a regular diet and evening snack (allowed as much as they wanted). | | Fair | Pre-tx wk: | G1: 2450 (1094) | Day 2: | G1: 17.9 (10.4) | | G1: 3.21 (2.85)
Setting: | | G2: cyproheptadine (N = 24) | Sex: | Exclusion: | Length of time in tx varied by speed of reaching target wt or withdrawal due to clinical deterioration. Max days: 90 | | Intent to treat: | G1: 1802 (746) | G2: 3023 (1103) | G1: 26.0 (9.2) | G2: 12.9 (9.5) | | G2: 3.07 (2.95)
Inpatient, University of Minnesota Hospitals, Minneapolis; New York Hospital - Cornell Medical Center, Westchester Division, White Plains, USA | | G3: placebo (N = 25) | Female: 100% | NR | | | No | G2: 1934 (940) | G3: 2390 (844) | G2: 21.7 (12.7) | G3: 14.5 (9.3) | | G3: 2.30 (3.45)
Enrollment period: | | Enrollment: | Race/ethnicity: | | | | Blinding: | G3: 1746 (542) | Diff between groups | G3: 22.0 (10.8) | Diff between groups (P = NR) | | Diff between groups (P = NS)
NR | | - 72 randomly assigned; - 54 completed:; - G1: 16; - G2: 18; - G3: 20 | NR | | | | Double | (P = NR) | (P < 0.04) G2 greater than G3 | (P = NR) | Diff between groups in change over time (P = NR)
| | | Age of onset of AN, mean (SD): | | | | Adverse events: Physical symptoms during tx, mean: | | Diff between groups | Day 7: | Day 28:
| | | 17.44 (4.6) (12 to 30) | | | | Day 7: | | (P < 0.06)G2 greater than G1 | G1: 19.7 (11.9) | G1: 13.1 (12.1)
| | | Duration of illness, yrs, mean (SD) (range): | | | | Moderate: | | | G2: 15.7 (9.4) | G2: 11.5 (9.4)
| | | 2.9 (2.3) (4 mo to 10 yrs). | | | | G1: 1.80 | | | G3: 14.4 (8.6) | G3: 13.6 (9.8)
| | | Marital status, N: | | | | G2: 1.83 | | | (P = NR) | Diff between groups (P = NR)
| | | Never married: 65 | | | | G3: 2.48 | | | | Diff between groups in change over time (P = NR)
| | | Divorced/Separated: 3 | | | | Severe: | | | Composite Depression Scores created from BDI and HSCL-90), mean (SD): | Composite Depression Scores created from BDI and HSCL-90, mean (SD): | | Days to Target Wt in patients achieving target wt, mean (SD):
| | | Married: 4. | | | | G1: 0.29 | | | Day 2: | Day 14: | | G1 (N = 17) 32.24 (17.37)
| | | Hollingshead social level score (SD): 2.0 (1.2) corresponding to hs grad and employment level between white-collar and administrative | | | | G2: 0.13 | | | G1: 5.1 (1.0) | G1: 4.0 (1.1) | | G2 (N = 20) 36.50 (19.53)
| | | No hx of binge eating, N: | | | | G3: 0.36 | | | G2: 4.7 (1.5) | G2: 3.6 (1.1) | | G3 (N = 16) 45.00 (18.34)
| | | 39 | | | | Day 21: | | | G3: 4.3 (1.2) | G3: 3.6 (1.0) | | Diff between G1 and G3 (P = 0.05)
| | | | | | | Moderate: | | | (P = NR) | Diff between groups (P = NR) | | G1 better than G3
| | | | | | | G1: 1.95 | | | Day 7: | Diff between groups in change over time (P = NR) | | Diff between G1 and G2 (P < 0.05)
| | | | | | | G2: 0.91 | | | G1: 4.3 (1.3) | Day 28: | | G2 better than G3
| | | | | | | G3: 1.80 | | | G2: 3.8 (1.2) | G1: 3.6 (1.1)
| | | | | | | Severe: | | | G3: 3.6 (1.0) | G2: 3.5 (1.2)
| | | | | | | G1: 0.14 | | | (P = NR) | G3: 3.5 (1.0)
| | | | | | | G2: 0 | | | | Diff between groups (interaction of G2 and wt gain vs G3, P < 0.01). Cyproheptadine + wt gain associated with less depression compared to placebo.
| | | | | | | G3: 0.28 | | | Hamilton Rating Scale, mean (SD): | Hamilton Rating Scale, mean (SD): | | Wt gain/day, kg, mean (SD):
| | | | | | | (P = NR) | | | Day 2: | Day 14: | | G1: 0.31 (0.17)
| | | | | | | G1: drowsiness, excitement, confusion, increased motor activity, tachycardia, dry mouth, constipation | | | G1: 17.3 (10.0) | G1: 14.6 (6.8) | | G2: 0.30 (0.19)
| | | | | | | G2: no pattern | | | G2: 19.6 (9.5) | G2: 13.4 (7.9) | | G3: 0.23 (0.12)
| | | | | | | G3: drowsiness, excitement, increased motor activity. | | | G3: 20.4 (7.8) | G3: 18.1 (7.8) | | Diff between groups (interaction of G2 and wt on day 7 of tx vs G3, P < 0.03). Greater day 7 wt gain on cyproheptadine associated with greater rate of wt gain over 28 days compared to placebo
| | | | | | | Funding: | | | (P = NR) | Diff between groups (P < 0.005)
| | | | | | | NIMH | | | Day 7: | Diff between G2 and G3
| | | | | | | | | | G1: 15.7 (6.9) | (P < 0.001)
| | | | | | | | | | G2: 17.1 (6.8) | G2 better than G3
| | | | | | | | | | G3: 17.8 (6.9) | Day 28:
| | | | | | | | | | (P = NR) | G1: 14.1 (6.9)
| | | | | | | | | | Diff between groups over time (P = NR) | G2: 13.2 (6.5)
| | | | | | | | | | | G3: 17.7 (8.5)
| | | | | | | | | | | | | Treatment Efficiency in AN subgroups, mean (SD):
| | | | | | | | | | | | | Bulimic (N = 33)
| | | | | | | | | | | | | G1: 4.99 (3.55)
| | | | | | | | | | | | | G2: 2.37 (1.78)
| | | | | | | | | | | | | G3: 3.65 (5.45)
| | | | | | | | | | | | | Diff between groups (P < 0.01)
| | | | | | | | | | | | | G1 better than G2
| | | | | | | | | | | | | Nonbulimic (N = 39): G1: 2.06 (1.51)
| | | | | | | | | | | | | G2: 4.23 (4.12)
| | | | | | | | | | | | | G3: 1.54 (1.21)
| | | | | | | | | | | | | Diff between groups (P < 0.01)
| | | | | | | | | | | | | G2 better than G3
| | | | | | | | | | | | | Treatment Failures (did not gain 2 kg after 6 wks of tx), N:
| | | | | | | | | | | | | G1: 6
| | | | | | | | | | | | | G2: 4
| | | | | | | | | | | | | G3: 9
| | | | | | | | | | | | | (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | G1: rhGH (0.05 mg/kg subcutaneously) received daily until discharge for a max of 28 days. | Comparison of mean responses between groups: two-sample t tests. Comparison of the median waiting time to achieve orthostasis between groups: log rank statistic. | Score: | NR | NR | NR | NR | Wt (kg): | Cardiovascular stability (2 consecutive mornings that patient was no longer orthostatic by pulse; orthostasis: change in pulse from a supine to standing position of > 20 beats per minute):
Hill et al., 2000 | To learn if rhGH improves the efficiency of tx protocols for malnourished AN patients who have medical/cardiovascular instability and require hospitalizations. | G1: rhGH (N = 8) | G1: 14.5 | DSM IV criteria for AN; sigly malnourished ( < 80% of IBW according to Frisancho's standard criteria). | G2: Placebo | | Good | | | | | G1: 38.3 | Estimate is diff in median time until patient no longer orthostatic
Setting: | | G2: placebo (N = 7) | G2: 15 | Exclusion: | All patients received standard clinical care for AN. | | Intent to treat: | | | | | G2: 40.7 | G1: 17 days
Inpatient at Children's Hospital Medical Center, Cincinnati, Ohio, USA | | Enrollment: | Range: 12–18 | Suicidal ideation; pre-existing medical conditions unrelated to AN which could complicate nutritional rehabilitation (e.g., inflammatory bowel disease, chronic lung disease, cardiac disease). | | | Yes | | | | | (P = NS) | G2: 37 days
Enrollment period: | | - 15 enrolled and completed | Sex: | | | | Blinding: | | | | | | Diff between groups (P < 0.02)
NR; 28 days | | | Female: | | | | Double | | | | | | Median length of hospitalization:
| | | G1: N = 7 | | | | Adverse events: | | | | | | G1: 32 days
| | | G2: N = 7 | | | | Monitored and none were reported | | | | | | G2: 39 days
| | | Race/ethnicity: | | | | Funding: | | | | | | Diff between groups (P = NS)
| | | NR | | | | NIMH, the Genentech Foundation for Growth and Development, the NIH, and the Veterans Administration | | | | | | Rate of wt gain:
| | | | | | | | | | | | | G1: 0.235 (0.077) kg/day
| | | | | | | | | | | | | G2: 0.166 (0.127) kg/day
| | | | | | | | | | | | | Diff between groups (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Subjects were randomly assigned to either initiation on fluoxetine or placebo prior to discharge. They began at a dosage of 20 mg/day and were adjusted over the 52 wks up to a max of 60 mg/day. Subjects evaluated every 4 wks after discharge (if status deteriorated sigly, then assessed every wk). Allowed to receive outpatient psychotherapy if they desired. | Survival analysis; Repeated measures MANOVAs for tx completers and drop-outs by condition, paired t-tests | Score: | YBOCS-ED (SD): | YBOCS-ED: | HDRS (SD): | HDRS (SD): | %ABW at entry (SD): | %ABW (SD):
Kaye et al., 2001 | To assess the efficacy and safety of fluoxetine (an SSRI) in the long-term relapse prevention (52 wks) among restricting-type AN patients following intensive cognitive-behavioral, and dietary inpatient intervention. Also examined effect of fluoxetine on core eating disorder symptoms, obsessionality, and depression. | G1: fluoxetine (N = 16) | G1: 23 (9) | Met DSM IV criteria for AN (restricting and restricting and purging types) when they were underwt | | | Fair | G1: 20.9 (11.2) | Change from baseline to 1 yr: | G1: 13.7 (10.7) | Change from baseline to 1 yr: | G1: 89 (6) | Change from baseline to 1 yr:
Setting: | | G1A: fluoxetine completers (N = 10) | G2: 22 (6) | Exclusion: | | | Intent to treat: | G2: 20.5 (9.5) | G1A: -8.4 (P < 0.05) | G2: 13.9 (10.4) | G1A: -8.2 (7.9) (P < 0.01) | G2: 89 (7) | G1A: 5.3 (5.3) (P < 0.01)
Single center; inpatient and outpatient; location: eating disorders tx program at Western Psychiatric Institute and Clinic, University of Pittsburgh Medical Center, Pittsburgh, PA, USA | | G1B:fluoxetine drop-outs (N = 6) | (P = NS) | Hx of binge-eating; concurrent severe medical or neurological conditions; concurrent or previous schizophrenia; concurrent or recent (within last 12 mos) alcohol or substance dependence; use of psychotropic meds within a mo before entry (exception was alprazolam) | | | No, data analyzed either on the sample of 35 who completed at least 30 days of tx or for those whom data available through the 1 yr FU (N = 13) | (P = NS) | G1B: 4.2 (P = NS) | (P = NS) | G1B: 0.3 (8.1) (P = NS) | (P = NS) | G1B: -1.2 (3.3) (P = NS)
Enrollment period: | | G2: placebo (N = 19) | G1A, G1B, G2A, G2B: NR | | | | Blinding: | G1A: 21.2 (11.2) | G2A: -14.3 (P = NS) | G1A: 13.4 (9.7) | G2A: 1.7 (2.1) (P = NS) | G1A: 88 (7) | G2A: 11.2 (11.9) (P = NS)
NR | | G2A: placebo completers (N = 3) | (P = NS) | | | | Double | G1B: 20.3 (13.3) | G2B: 0.8 (P = NS) | G1B: 14.3 (13.1) | G2B: -3.5 (10.5) (P = NS) | G1B: 92 (5) | G2B: -0.2 (6.7) (P = NS)
| | G2B: placebo drop-outs (N = 16) | Sex: | | | | Adverse events: | G2A: 25.7 (2.9) | Diff between G1 and G2 (P = NS) | G2A: 4.0 (5.3) | Diff between G1 and G2 | G2A: 89 (12) | Diff between G1 and G2
| | Enrollment: | Female: 100% | | | | NR | G2B: 19.5 (10.1) | Diff between groups in change over time (P = NS) | G2B: 15.8 (10.0) | (P = NS) | G2B: 90 (6) | (P = NS)
| | - 95 screened who were admitted to the eating disorder inpatient unit; - 39 enrolled and randomized (G1: N = 19; G2: N = 20); - 35 took fluoxetine or placebo for at least 30 days (G1: N = 16; G2: N = 19); - 13 completers remained at 1 yr FU (G1: N = 10; G2: N = 3) | Race/ethnicity: | | | | Funding: | (P = NR) | | (P = NR) | Diff between groups in change over time (P = NS) | (P = NS) | Diff between groups in change over time (P = NS)
| | (P = 0.006) | NR | | | | Eli Lilly Corporation, NIMH | | Abstinence/remission rates: | HAM-A (SD): | HAM-A: | Low lifetime %ABW (SD):
| | | Age of onset (SD): | | | | | | NR | G1: 11.3 (7.5) | Change from baseline to 1 yr: | G1: 70 (8)
| | | G1: 16 (5) | | | | | | | G2: 11.2 (6.4) | G1A: -5.1 (P < 0.01) | G2: 73 (7)
| | | G2: 18 (5) | | | | | | | (P = NS) | G1B: -0.8 (P = NS) | (P = NS)
| | | (P = NS) | | | | | | | G1A: 10.6 (1.7) | G2A: -2.0 (P = NS) | G1A, G1B, G2A, G2B: NR
| | | G1A, G1B, G2A, G2B: NR | | | | | | | G1B: 12.5 (4.4) | G2B: -2.4 (P = NS) | (P = NS)
| | | (P = NS) | | | | | | | G2A: 5.3 (3.9) | Diff between G1 and G2
| | | | | | | | | | G2B: 12.3 (1.5) | (P = NS)
| | | | | | | | | | (P = NR) | Diff between groups in change over time (P = NS)
| | | | | | | | | | Y-BOCS (SD): | Y-BOCS (SD):Change from baseline to 1 yr: | High lifetime %ABW (SD):
| | | | | | | | | | G1: 15.0 (10.1) | G1A: -8.6 (12.7) (P < 0.10) | G1: 110 (24)
| | | | | | | | | | G2: 14.3 (7.7) | G1B: 8.6 (7.2) (P < 0.10) | G2: 112 (16)
| | | | | | | | | | (P = NS) | G2A: -1.0 (5.6) (P = NS) | (P = NS)
| | | | | | | | | | G1A: 16.8 (9.6) | G2B: -1.6 (6.9) (P = NS) | G1A, G1B, G2A, G2B: NR
| | | | | | | | | | G1B: 12.0 (11.2) | Diff between G1 and G2 | (P = NS)
| | | | | | | | | | G2A: 8.0 (8.5) | (P = NS)
| | | | | | | | | | G2B: 15.5 (7.2) | Diff between groups in change over time (P = NS)
| | | | | | | | | | (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Enrolled subjects were randomized either to the estrogen or non-meds control group. Tx included Premarin (0.625 mg, days 1–25), Provera (5 mg, days 16–25) or oral contraceptive. Biochemical indicators including bone density and serum hormone levels assessed at 6-mo intervals for an avg of 1.5 yrs. No psychosocial measures assessed. | Students t-tests and Fisher's Exact Test used to evaluate between group diffs on the primary variables of interest including log-transformed spinal bone density. ANCOVAs used to test for interactions between the clinical and biochemical variables in affecting bone density changes over time. | Score: | NR | NR | NR | | Wt, kg mean (SD): | Wt, kg mean (SD):
Klibanski et al., 1995 | To assess the efficacy and safety of estrogen and progestin replacement therapy for reducing bone loss in patients with AN at 6-mo intervals over an avg of 1.5 yrs. | G1: estrogen/progestin (N = 22) | G1: 23.7 (7.2) | Women who met DSM III-R criteria for AN | All participants also took 1500 mg calcium. | | Fair | | | | | G1: 43.03 (7.3) | G1: NR
Setting: | | G2: control (N = 26) | G2: 25.8 (6.6) | Exclusion: | | | Intent to treat: | | | | | G2: 41.0 (5.6) | G2: NR
Single center; inpatient evaluation, otherwise outpatient location: General Clinical Research Center and Eating Disorders Unit, Massachusetts General Hospital; Boston, MA, USA | | Enrollment: | Range: 16.3–42.5 | Other illnesses; taking meds that could impact bone density (e.g., thyroid hormone, antiseizure meds, or glucocorticoids) | | | NR | | | | | (P = NR) | (P = NR)
Enrollment period: | | - 48 women were enrolled and randomized who were recruited from the hospital's Eating Disorders Clinic and from psychiatrists in the community; - 44 completers | (P = NS) | | | | Blinding: | | | | | % IBW, mean (SD): | %IBW, mean (SD):
NR | | G1: N = 19 | Sex: | | | | NR | | | | | G1: 72 (9) | G1: NR
| | G2: N = 25 (P = NR) | Female: 100% | | | | Adverse events: | | | | | G2: 72 (8) | G2: NR
| | | Race/ethnicity: | | | | Depression: | | | | | (P = NS) | (P = NR)
| | | NR | | | | G1: N = 1 | | | | | % Body fat, mean (SD): | % Body fat, mean (SD):
| | | | | | | G2: N = 0 | | | | | G1: 15 (5) | G1: NR
| | | | | | | (P = NR) | | | | | G2: 14 (4) | G2: NR
| | | | | | | Hyperlipidemia: | | | | | (P = NS) | (P = NR)
| | | | | | | G1: N = 1 | | | | | Bone density, mg K _ 2 _ HPO _ 4 _ /cm ^ 3 ^ mean (SD): | Bone density, mg K _ 2 _ HPO _ 4 _ /cm ^ 3 ^ mean (SD):
| | | | | | | G2: N = 0 | | | | | G1: 124 (25) | G1: 128 (26)
| | | | | | | (P = NR) | | | | | G2: 134 (28) | G2: 132 (31)
| | | | | | | Funding: | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | NIH and Rubenstein Foundation | | | | | Serum hormone levels, mean (SD): | Serum hormone levels, mean (SD):
| | | | | | | | | | | | Ethinyl estradiol, pmol/L: | G1: NR
| | | | | | | | | | | | G1: 81 (29) | G2: NR
| | | | | | | | | | | | G2: 77 (44) | (P = NS)
| | | | | | | | | | | | (P = NS)
| | | | | | | | | | | | Testosterone, nmol/L:
| | | | | | | | | | | | G1: 1.2 (0.7)
| | | | | | | | | | | | G2: 1.5 (0.8)
| | | | | | | | | | | | (P = NS)
| | | | | | | | | | | | Unbound Testosterone, pmol/L:
| | | | | | | | | | | | G1: 14 (7)
| | | | | | | | | | | | G2: 16 (10)
| | | | | | | | | | | | (P = NS)
| | | | | | | | | | | | IGF-1, U/L:
| | | | | | | | | | | | G1: 223 (102)
| | | | | | | | | | | | G2: 229 (89)
| | | | | | | | | | | | (P = NS)
| | | | | | | | | | | | TT _ 3 _ , nmol/L:
| | | | | | | | | | | | G1: 1.5 (0.3)
| | | | | | | | | | | | G2: 1.6 (0.4)
| | | | | | | | | | | | (P = NS)
| | | | | | | | | | | | | Remission/Recovery = 85% IBW and spontaneous return of menses:
| | | | | | | | | | | | | G1: N = 2
| | | | | | | | | | | | | G2: N = 6
| | | | | | | | | | | | | (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Doses of 150 and 300 μg transdermal testosterone (Patches) administered to two groups on group given placebo for a period of 3 wks. | ANOVA to compare baseline characteristics and Wilcoxon rank-sums test for non-normal distributions | Score: | NR | NR | BDI (SEM): | BDI (SEM): | %IBW (SD): | BMI:
Miller et al., 2005 | Investigate effectiveness of low-dose testosterone replacement in increasing bone formation, depression and spatial abilities of women with AN and relative androgen deficiency. | G1: Testosterone (N = 24) | G1: 25 (1) | Women; aged 18–50 yrs; DSM IV criteria for AN; < 85%IBW; amenorrhea for at least 3 mos; all psychiatric manifestations of AN; serum free testosterone level < median of reference range for premenopausal women; no oral contraceptives, progesterone derivatives, glucocorticoids, anabolic agents or any meds known to affect bone metabolism within 3 mos before study enrollment; no fracture within one yr of participation. | Antidepressant use allowed, no sig diff in use between G1 and G2 at baseline. | Repeated measures ANOVA for biomarkers and mood. Data from two meds groups combined for analysis on tx effects after determining that there was no statistically sig diff between groups. For analysis of cognitive abilities, ANCOVA was used. | Fair | | | G1: 12 (2) | G1: 15.1 (2.6) | G1: 76.9 (1.6) | G1: NR
Setting: | | G2: Placebo (N = 9) | G2: 22 (1) | Exclusion: | | | Intent to treat: | | | G2: 14 (3) | G2: 19.3 (5.2) | G2: 75.6 (2.5) | G2: NR
MA General Hospital, Boston, USA | | Enrollment: | Range: 18–50 | NR | | | NR | | | | Diff between groups (P = 0.02) | | Diff between groups (P = NR)
Enrollment period: | | - 38 women were enrolled in the study.; - 5 dropped out, resulting in 33 participants.; - 33 individuals randomized to receive testosterone or placebo. | (P = NS) | | | | Blinding: | | | | Diff between groups in change over time (P = 0.03) | | Diff between groups in change over time (P = 0.02)
NR | | | Sex: | | | | Participants and investigators were blind to group assignment. | | | | | Free testosterone, pmol/liter (SEM): | Free testosterone, pmol/liter (SEM):
| | | Female: 100% | | | | Adverse events: | | | | | G1: 8.9 (1.1) | G1: 26.7 (3.0)
| | | Race/ethnicity: | | | | Mild skin irritation at the patch site (G1 = 3, G2 = 1). 1 participant in G1 with a hx of affective disorder reported increased depression and anxiety after 10 days of tx. Other side effects included increased fatigue and vertigo (G2 = 1), nausea (G2 = 1) and life threatening wt loss (G2 = 1, G1 = 1) | | | | | G2: 9.1 (1.2) | G2: 8.9 (1.5)
| | | NR | | | | Funding: | | | | | | Diff between groups (P = NR)
| | | Mos since last menstrual period (SEM): | | | | NIH | | | | | | Diff between groups in change over time (P < 0.0001)
| | | G1: 20 (5) | | | | | | | | | | G1 greater increase than G2
| | | G2: 14 (6) | | | | | | | BDI in depressed subgroup (score > 10): | BDI in depressed subgroup: | Total testosterone, nmol/liter (SEM): | Total testosterone, nmol/liter (SEM):
| | | Bone Mineral Density at L4, mg/cc of K2 HPO4 (SEM): | | | | | | | G1: 20.4 (2.1) | G1: 15.1 (2.6) | G1: 0.9 (0.4) | G1: 2.4 (0.2)
| | | G1: 126 (5) | | | | | | | G2: 19.8 (3.8) | G2: 19.3 (5.2) | G2: 0.9 (0.3) | G2: 0.8 (0.1)
| | | G2: 135 (6) | | | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in change over time (P = 0.02) | | Diff between groups in change over time (P < 0.0001)
| | | | | | | | | | | G1 better than G2 | | G1 greater increase than G2
| | | | | | | | | | | | Estradiol, nmol/liter (SEM): | Estradiol, nmol/liter (SEM):
| | | | | | | | | | | | G1: 0.07 (0.007) | G1: 0.07 (0.009)
| | | | | | | | | | | | G2: 0.07 (0.01) | G2: 0.06 (0.01)
| | | | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | | | | SHBG, nmol/liter (SEM): | SHBG, nmol/liter (SEM):
| | | | | | | | | | | | G1: 113.9 (14.1) | G1: 114.1 (14.3)
| | | | | | | | | | | | G2: 103.6 (20.1) | G2: 116.1 (16.0)
| | | | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | | | | Dehydroepiandrosterone Sulphate, nmol/liter (SEM): | Dehydroepiandrosterone Sulphate, nmol/liter (SEM):
| | | | | | | | | | | | G1: 341 (26) | G1: 338 (33)
| | | | | | | | | | | | G2: 354 (37) | G2: 394 (53)
| | | | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | | | | IGF-I, nmol/liter (SEM): | IGF-I, nmol/liter (SEM):
| | | | | | | | | | | | G1: 30 (3) | G1: 32 (4)
| | | | | | | | | | | | G2: 26 (4) | G2: 28 (5)
| | | | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | | | | PICP, μg/liter (SEM): | PICP, μg/liter during drug administration (SEM):
| | | | | | | | | | | | G1: 132 (12) | G1: NR
| | | | | | | | | | | | G2: 119 (19) | G2: NR
| | | | | | | | | | | | | Diff between groups (P = NR) diff between groups in change over time (P = 0.02)
| | | | | | | | | | | | Osteocalcin, μg/liter (SEM): | Osteocalcin, μg/liter (SEM):
| | | | | | | | | | | | G1: 13.9 (1.7) | G1: NR
| | | | | | | | | | | | G2: 11.1 (2.0) | G2: NR
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | | Bone Specific Alkaline Phosphatase, μkat/liter (SEM): | Bone Specific Alkaline Phosphatase, μkat/liter (SEM):
| | | | | | | | | | | | G1:.38 (.02) | G1: NR
| | | | | | | | | | | | G2:.37 (.04) | G2: NR
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | | N-telopeptide, nM BCE (SEM): | N-telopeptide, nM BCE (SEM):
| | | | | | | | | | | | G1: 16 (1) | G1: NR
| | | | | | | | | | | | G2: 18 (3) | G2: NR
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Meds management done within the context of the 3-mo refeeding tx offered on the unit. G1 treated with clomipramine at a mean dosage of 57.69 mg/d (SD = 25.79). G2 treated with fluoxetine at a mean dosage of 28 mg/d (SD = 10.32) and G3 treated with amisulpride at a mean dosage of 50 mg/d (SD = 0). | ANOVA and Tukey's honestly sig diff were used to compare percentage wt increases of the 3 groups. T-tests used for paired data to compare absolute wt values of each group. The McNemar test for present/absent dichotomous variables used for the variables of wt phobia, body image, amenorrhea, bingeing and purging. | Score: | Bingeing | Bingeing: | Wt phobia: | Wt Phobia: | Wt in kgs (SD): | Wt in kgs (SD):
Ruggiero et al., 2001 | Compare amisulpride, clomipramine, and fluoxetine in treating AN and improving attitudes toward wt gain, eating, body shape and fear of fatness. | G1: clomipramine (N = 13) | G1: 23.69 (4.57) | Dx of restricting type AN according to DSM IV, severe underwt condition needing urgent wt restoration, capacity to cooperate according to current health. | | | Poor | G1: 0 | G1: 0 | G1: 61.53% | G1: 30.76% | G1: 37.62 (9.80) | G1: 38.84 (9.38) (P = NS)
Setting: | | G2: fluoxetine (N = 10) | G2: 24.50 (5.06) | Exclusion: | | | Intent to treat: | G2: 0 | G2: 40% | G2: 60% | G2: 50% | G2: 40.90 (6.98) | G2: 42.75 (7.54) (P = 0.04)
Inpatient Endocrinology Department, Istituto Auxologico, Milan University Hospital, Milan, Italy | | G3: amisulpride (N = 12) | G3: 24.33 (5.76) | Being younger than 17 yrs, not consenting, not completing refeeding tx, not speaking Italian with sufficient fluency, showing clear psychiatric comorbidity such as, depression, anxiety or obsessive-compulsive disorder and delusional body image related thinking. | | | NR | G3: 0 | G3: 25% | G3: 91.66% | G3: 75% | G3: 38.42 (8.33) | G3: 42.66 (10.09) (P = 0.01)
Enrollment period: | | Enrollment: | (P = NR) | | | | Blinding: | | Diff between groups (P = NS) | (P = NR) | Diff between groups (P = NS) | (P = NR) | Diff between groups (P = NS)
March 1997 to November 1998 | | Participants selected from a larger population of 164 ED patients treated in the endocrinology department. | Sex: | | | | NR | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | NR | | | | Adverse events: | Purging: | Purging: | Body Image Disturbance: | Body Image Disturbance: | BMI: | BMI:
| | | Height: mean cm (SD): | | | | NR | G1: 0 | G1: 0 | G1: 46.15% | G1: 30.76% | G1: 14.69 | G1: 15.17
| | | G1: 160.00 (9.17) | | | | Funding: | G2: 0 | G2: 30% | G2: 50% | G2: 30% | G2: 15.97 | G2: 16.70
| | | G2: 160.40 (6.59) | | | | NR | G3: 0 | G3: 25% | G3: 75% | G3: 66.66% | G3: 14.44 | G3: 16.03
| | | G3: 163.42 (4.03) | | | | | | Diff between groups (P = NS) | (P = NR) | Diff between groups (P = NS) | (P = NR) | Diff between groups (P = NR)
| | | (P = NR) | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | Race/ethnicity: | | | | | | Abstinence/Remission: | | | Amenorrhea: | Amenorrhea:
| | | NR | | | | | | NR | | | G1: 84.61% | G1: 53.84%
| | | | | | | | | | | | G2: 70% | G2: 70%
| | | | | | | | | | | | G3: 91.66% | G3: 66.66%
| | | | | | | | | | | | (P = NR) | Diff between groups (P = NS)
| | | | | | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SE): | Inclusion: | Cisapride, 10 mg orally, three times daily. Patients were all expected to consume between 2500 to 3500 kCal per day. At entry to the trial, patients were asked to fast overnight, given a meal and measures of gastric emptying, lag and subjective states were evaluated. A full blood examination was also done. | Slopes representing change over time for each patient using the least squares method. The slopes for change were correlated among the variables. | Score: | NR | NR | BDI (SE): | Change in BDI (SE): | Wt, kg (SE): | Change in Wt, kg (SE):
Szmukler et al., 1995 | Test effectiveness of cisapride in treating gastric and psychological features associated with AN | G1: Cisapride (N = 16) | G1: 21.5 (0.8) | DSM III-R criteria for current AN, aged 18–40 yrs. Eligible if they had bulimic symptoms as long as the criteria for current AN still met. | | | Poor | | Global Improvement in Eating Symptoms (SE): | G1: 28.6 (2.6) | G1: - 9.0 (2.6) | G1: 40.5 (1.7) | G1: 5.1 (0.5)
Setting: | | G2: Placebo (N = 13) | G2: 22.5 (2.0) | Exclusion: | | | Intent to treat: | | G1: 2.50 (0.27) | G2: 26.5 (3.2) | G2: - 6.8 (3.6) | G2: 41.6 (1.8) | G2: 5.7 (0.6)
Two inpatient tx centers for AN Australia | | Enrollment: | Diff between groups | Concurrent illness that would affect gastric emptying. | | | NR | | G2: 3.38 (0.18) | | Diff between groups (P = NS) | | Diff between groups (P = NR)
Enrollment period: | | - Consecutive inpatients at tx centers for AN; - Patients recruited soon after admission; however, meds trial started on avg 9 days after admission; - 50 patients invited to participate in the study and 34 agreed.; - Of these, 5 did not progress beyond 2 wks.; - Gastric emptying patterns in 10 normal female controls (university students and staff) also studied over 2 time periods | (P = NS) | | | | Blinding: | | Diff between groups (P = NR) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
NR | | | Sex: | | | | Yes | | Diff between groups in change over time (P = 0.02) | Visual Analog Scale (SE): | Change in Visual Analog Scale (SE):
| | | NR | | | | Adverse events: | | G1 better than G2 | Miserable: | Miserable:
| | | Race/ethnicity: | | | | One patient reported loose motions without abdominal pain. | | | G1: 56 (10) | G1: - 15 (12)
| | | NR | | | | Funding: | | | G2: 33 (8) | G2: - 4 (12)
| | | Height, cms (SE): | | | | Janssen-Cilag patienty Ltd. | | | | Diff between groups (P = NR)
| | | G1: 163.5 (1.7) | | | | | | | | Diff between groups in change over time (P = NS)
| | | G2: 166.5 (1.4) | | | | | | | Tense: | Tense:
| | | Diff between groups | | | | | | | G1: 54 (9) | G1: - 17 (10)
| | | (P = NS) | | | | | | | G2: 35 (8) | G2: - 6 (11)
| | | Duration of illness, mos (SE): | | | | | | | | Diff between groups (P = NR)
| | | G1: 39.5 (11.4) | | | | | | | | Diff between groups in change over time (P = NS)
| | | G2: 23.5 (4.8) | | | | | | | Bloated: | Bloated:
| | | Diff between groups | | | | | | | G1: 57 (9) | G1: - 16 (11)
| | | (P = NS) | | | | | | | G2: 58 (9) | G2: - 7 (7)
| | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | | Fat: | Fat:
| | | | | | | | | | G1: 59 (9) | G1: - 20 (11)
| | | | | | | | | | G2: 55 (8) | G2: 0 (7)
| | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | | Hot: | Hot:
| | | | | | | | | | G1: 23 (8) | G1: - 7 (9)
| | | | | | | | | | G2: 27 (8) | G2: 1 (8)
| | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | | Hungry: | Change in Hunger:
| | | | | | | | | | G1: 8 (3) | G1: 27 (10)
| | | | | | | | | | G2: 32 (8) | G2: - 9 (7)
| | | | | | | | | | (P < 0.01) | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in change over time (P < 0.02)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Double-blind cross-over design. After 1 wk baseline, patients began 2 meds periods of 3 wks each. 13 patients received daily dose of 300 mg (100 mg t.i.d.) and 5 received 400 mg (200 mg b.i.d.). Inpatient tx as usual. | Inter-group comparison (Mann-Whitney U-test) | Score: | EAT, mean (SD): | EAT, mean (SD): | BAT, mean (SD): | BAT, mean (SD): | Wt (kg), mean (SD): | Wt change (g/day), mean (SD):
Vandereycken, 1984 | To investigate the use of sulpiride in AN | G1: sulpiride - placebo sequence (N = 9) | G1: 23.2 (6.5) | Female dx of AN (DSM III criteria), no additional drug tx (except hypnotics) | | Evidence table only contains outcomes prior to cross-over. | Poor | Preoccupation with eating/body wt: | Preoccupation with eating/body wt: | G1: 42.6 (11.4) | G1: 36.8 (12.9) (P = NR) | G1: 40.4 (4.6) | G1: 153.8 (91.0) (P = NR)
Setting: | | G2: placebo - sulpiride sequence (N = 9) | G2: 23.7 (9.6) | Exclusion: | | | Intent to treat: | G1: 50.9 (26.0) | G1: 39.0 (27.2) (P = NR) | G2: 30.4 (12.8) | G2: 27.7 (8.1) (P = NR) | G2: 38.3 (4.3) | G2: 92.6 (49.4) (P = NR)
Inpatient at the University Psychiatric Center St-Jozef in Kortenberg, Belgium | | Enrollment: | (P = NS) | NR | | | Yes | G2: 31.0 (17.2) | G2: 17.8 (8.9) (P = NR) | (P = 0.05) | Diff between groups (P = NS) | (P = NS) | Diff between groups (P = NR)
Enrollment period: | | NR | Sex: | | | | Blinding: | (P = 0.05) | Diff between groups (P = 0.03) | | Diff between groups in change over time (P = NR) | Wt vs ideal wt (%) (SD): | Diff between groups in change over time (P = NS)
NR | | | Female: | | | | Double | G2 lower than G1 | G2 lower than G1 | | | G1: 71.6 (8.2)
| | | G1: 100% | | | | Adverse events: | AN Behavior, mean (SD): | Diff between groups in change over time (P = NR) | | | G2: 67.6 (7.2)
| | | G2: 100% | | | | None reported | Nurse observation: | AN Behavior, mean (SD): | | | (P = NS)
| | | Race/ethnicity: | | | | Funding: | G1: 17.7 (6.7) | Nurse observation: | | | Wt vs premorbid wt (%) (SD):
| | | NR | | | | Drug and placebo provided by Laboratoire Delagrange, Belgium | G2: 18.7 (5.5) | G1: 15.1 (5.6) (P = NR) | | | G1: 70.7 (5.9)
| | | Duration of illness (mos), mean (SD): | | | | | (P = NS) | G2: 14.1 (4.4) (P = NR) | | | G2: 69.9 (6.4)
| | | G1: 51.8 (49.2) | | | | | Psychiatrist observation: | Diff between groups (P = NS) | | | (P = NS)
| | | G2: 74.9 (106.9) | | | | | G1: 10.7 (6.9) | Diff between groups in change over time (P = NR) | | | Wt change (g/day) during 1-wk pre-tx phase, mean (SD):
| | | (P = NS) | | | | | G2: 9.5 (7.7) | Psychiatrist observation: | | | G1: 86.4 (126.8)
| | | | | | | | (P = NS) | G1: 12.2 (9.3) (P = NR) | | | G2: 141.0 (115.5)
| | | | | | | | | G2: 7.0 (6.2) (P = NR) | | | (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)

Evidence Table 2. Medication plus behavioral intervention trials for anorexia nervosa

| | | | | | | | Eating Related Measures | | Psychological/Psychiatric Measures | | Biomarkers
Study Description | Objective | Design | Patient Characteristics | Inclusion/Exclusion Criteria | Treatment | Statistical Methods | Quality | Baseline | Outcomes | Baseline | Outcomes | Baseline | Outcomes
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | G1: 40 mg/day | Paired and unpaired student's t test, Wilcoxon, Mann-Whitney U | Score: | EDE, restraint, mean (SD): | EDE, restraint, mean (SD): | BDI, mean (SD): | BDI, mean (SD): | BMI, mean (SD): | BMI, mean (SD):
Ricca et al., 1999 | To compare the efficacy of venlafaxine and fluoxetine in the tx of atypical AN when combined with CBT. | G1: Fluoxetine (N = 13) | 19.0 (3.7) | Atypical AN defined as all DSM IV criteria except one and criteria for other ED not fulfilled. Atypical AN = all criteria for AN except: 1) amenorrhea 2) wt loss (body wt above the dx threshold). | G2: 75 mg/day | | Poor | G1: 3.17 (1.23) | G1: 2.57 (1.15) | G1: 12.50 (8.75) | G1: 7.25 (4.27) | G1: 15.84 (0.46) | G1: 18.7 (1.1)
Setting: | | G2: Venlafaxine (N = 13) | G1: 19.1 (3.6) | Exclusion: | Both had CBT provided wkly on an outpt basis. | | Intent to treat: | G2: 3.40 (1.26) | Diff over time (P < 0.05) | G2: 16.25 (9.32): | Diff over time (P < 0.01) | G2: 15.67 (0.59) | Diff over time (P < 0.001)
Outpatient ED clinic, Italy | | Enrollment: | G2: 18.9 (3.8) | Illiteracy, mental retardation, concurrent medical condition that would preclude use of antidepressants, psychotropic drugs in the previous 2 mo (except for low doses of anxiolytic or hypnotic compounds). | Tx: 6 mo | | No | (P = NR) | G2: 2.74 (0.85) | (P = NR) | G2: 7.67 (3.96) | (P = NS) | G2: 18.3 (1.3)
Enrollment period: | | - 26 Enrolled; - 24 completed (1 drop out in each group) | (P = NS) | | | | Blinding: | | Diff over time (P < 0.001) | | Diff over time (P < 0.001) | | Diff over time (P < 0.001)
June 1, 1997 - April 31, 1998 | | | Sex: | | | | No | | Diff between groups (P = NR) | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | Female: 100% | | | | Adverse events, 2 stopped tx N: | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | Race/ethnicity: | | | | G1: 1 nausea | EDE, eating concerns, mean (SD): | EDE, eating concerns, mean (SD): | STAI-State, mean (SD): | STAI-State, mean (SD):
| | | NR | | | | G2: 1 constipation | G1: 3.14 (1.47) | G1: 2.66 (1.07) | G1: 41.00 (8.06) | G1: 51.08 (9.94)
| | | Marital Status, N: Unmarried: | | | | Funding: | G2: 3.12 (2.12) | Diff over time (P = 0.05) | G2: 45.17 (9.02) | Diff over time (P = 0.001)
| | | G1: 9 | | | | NR | (P = NR) | G2: 2.65 (1.76) | (P = NR) | G2: 38.00 (4.88)
| | | G2: 7 | | | | | | Diff over time (P < 0.05) | | Diff over time (P < 0.001)
| | | Married: | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | G1: 2 | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P < 0.001)
| | | G2: 3 | | | | | | | | G1 increased in state anxiety while G2 decreased
| | | Separated/Divorced: | | | | | EDE, wt concerns, mean (SD): | EDE, wt concerns, mean (SD): | STAI-Trait, mean (SD): | STAI-Trait, mean (SD):
| | | G1: 1 | | | | | G1: 2.85 (1.46) | G1: 2.54 (1.25) | G1: 44.17 (9.16) | G1: 45.50 (8.47)
| | | G2: 2 | | | | | G2: 3.40 (1.73) | Diff over time (P = 0.05) | G2: 50.25 (10.0) | Diff over time (P = NS)
| | | (P = NR) | | | | | (P = NR) | G2: 3.08 (1.41) | (P = NR) | G2: 39.67 (4.83)
| | | Education, N: | | | | | | Diff over time (P < 0.05) | | Diff over time (P < 0.001)
| | | Junior HS: | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | G1: 4 | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P < 0.001)
| | | G2: 3 | | | | | | | | G1 showed no change while G2 decreased in trait anxiety
| | | Senior HS: | | | | | EDE, shape concerns, mean (SD): | EDE, shape concerns, mean (SD):
| | | G1: 8 | | | | | G1: 3.62 (1.04) | G1: 3.16 (0.86) diff over time (P < 0.01)
| | | G2: 9 | | | | | G2: 3.88 (1.77) | G2: 3.48 (0.89) diff over time (P < 0.01)
| | | Employment Status, N: Unemployed: | | | | | (P = NR) | Diff between groups (P = NR)
| | | G1: 0 | | | | | | Diff between groups in change over time (P = NS)
| | | G2: 1
| | | Employed:
| | | G1: 4
| | | G2: 5
| | | Student:
| | | G1: 8
| | | G2: 6
| | | (P = NR)
| | | Axis I Dx per SCID for DSM III-R:
| | | Dysthymia:
| | | G1: 4
| | | G2: 4
| | | Adjustment disorder with depressed mood (ADDM)
| | | G1: 2
| | | G2: 3
| | | OCD:
| | | G1: 1
| | | G2: 1
| | | Diff between groups (P = NR)

Evidence Table 3. Behavioral intervention trials for adults with anorexia nervosa

| | | | | | | | Eating Related Measures | | Psychological/Psychiatric Measures | | Biomarkers
Study Description | Objective | Design | Patient Characteristics | Inclusion/Exclusion Criteria | Treatment | Statistical Methods | Quality | Baseline | Outcomes | Baseline | Outcomes | Baseline | Outcomes
Author, year: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | All subjects wore a warming vest on their chest for 3 hr a day for 21 days. All vests were plugged in. Wearing the vest required the subject to remain within the radius of the power cord. | Descriptive Statistics | Score: | NA | NA | NA | NA | BMI, mean (SD): | BMI, mean (SD):
Birmingham et al., 2004 | To determine if warming therapy increases the rate of weight gain in patients with AN. | G1: Warming treatment (N = 10) | Total Sample: 28.4 (6.6) | Female, between the ages of 17 – 50, admitted to the eating disorders inpatient unit at St. Paul's Hospital. | G1: Vests were set permanently at medium heat. | Statistical tests used = NR | Poor | | | | | Total sample: 17.7 (2.8) | Total sample: 18.4 (2.9)
Setting: | | G2: Control (N = 11) | G1: 26.4 (4.8) | Exclusion: | G2: Vests were set permanently in the off position. | | Intent to treat: | | | | | G1: 17.5 (3.2) | G1: 18.0 (3.6)
Inpatient | | Enrollment: | G2: 30.2 (7.6) | Gravid, male gender, age over 50, diabetes mellitus, untreated hypothyroidism, use of beta blockers. | | | NR | | | | | G2: 17.9 (2.4) | G2: 18.8 (2.1)
Vancouver, British Columbia, Canada | | Assessed: N = 32 | (P = NS) | | | | Blinding: | | | | | (P = NS) | Diff over time (P = NR)
Enrollment period: NR | | Enrolled: N = 21 | Sex: | | | | Patient blinded. Researcher or Assessor Blinding = NR | | | | | | Diff between groups (P = NS)
| | Completed: N = 18 | Female = 100% | | | | Adverse events: | | | | | | Diff between groups in change over time (P = NR)
| | G1: 10 | Race/ethnicity: | | | | NR | | | | | | Change in BMI, mean (SD):
| | G2: 8 | NR | | | | Funding: | | | | | | Total sample: 0.59 (1.2)
| | | Length of AN, yrs, mean (SD): | | | | NR | | | | | | G1: 0.60 (1.2)
| | | Total Sample: 13.6 (6.7) | | | | | | | | | | G2: 0.58 (1.1)
| | | G1: 11.7 (7.1) | | | | | | | | | | Diff over time (P = NR)
| | | G2: 15.0 (6.3) | | | | | | | | | | Diff between groups (P = NS)
| | | (P = NS) | | | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Four assessments: 1) PreTx, 2) after 6 mo of tx (18 sessions), 3) after 6 mo FU (6 booster sessions), 4) after 12 mo FU. | Repeated measures ANOVA with appropriate contrasts for parametric tests; nonparametric tests for diff scores for clinical ratings and self-reports. No means given, only F statistics and P values. | Score: | NR | Post Treatment | | Post-tx: | | Post Treatment:
Channon et al., 1989 | To investigate the effectiveness of an output CBT tx for AN and compare it to BT alone, and control for “usual care.” | G1: CBT (N = 8) | G1: 21.63 (5.88) | Dx AN per Russell's (1983) classification; bulimic features accepted as long as also met Russell's dx | G1: Self-monitoring and daily food planning, information, education, Identitication of dysfunctional thoughts and challenging them. | Comparisons: | Fair | | EDI, drive for thinness: | | BDI: | BMI, mean (SD): | BMI
Setting: | | G2: BT (N = 8) | G2: 24.13 (5.77) | Exclusion: | G2: Daily diary, self-monitoring, daily planning, Construction of graded hierarchies of feared foods and situations and graded exposure. Relaxation and distraction techniques. | G1 vs. G2 | Intent to treat: | | G1: NR (P = NR) | | G1: NR (P = NR) | G1: 14.85 (1.10) | G1: NR (P = NR)
Outpatient ED Clinic of the Maudsley Hospital, London, UK | | G3: Control (N = 8) | G3: 25.75 (7.19) | NR | G3: 1/2 hour tx session, eclectic therapy | (G1 + G2) vs. G3 | Yes | | G2: NR (P = NR) | | G2: NR (P = NR) | G2: 16.06 (1.42) | G2: NR (P = NR)
Enrollment period: NR | | Enrollment: | (P = NS) | | | | Blinding: | | G3: NR (P = NR) | | G3: NR (P = NR) | G3: 14.90 (1.49) | G3: NR (P = NR)
| | - 34 referred; - 24 met criteria and enrolled; - Dropouts, N: G1: 0; G2: 1; G3: 2. | Sex: | | | | NA | | Diff between groups (P = NS) | | Diff between groups (P = NS) | (P = NS) | Diff between groups (P = NS)
| | 3 dropped out during FU and still provided assessment data (included in analysis) | Female: 100% | | | | Adverse events: | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | Race/ethnicity: | | | | 2 patients in G1, 1 patient in G2 and 4 patients in G3 hospitalized for severe and progressive wt loss | | EDI, body dissatisfaction: | | MOCI: | | 6 mo:
| | | NR | | | | Funding: | | G1: NR (P = NR) | | G1: NR (P = NR) | | M-R menstrual:
| | | Age of Onset, mean (SD): | | | | Bethlem-Maudsley Research Fund | | G2: NR (P = NR) | | G2: NR (P = NR) | | G1: NR (P = NR)
| | | G1: 16.50 (3.82) | | | | | | G3: NR (P = NR) | | G3: NR (P = NR) | | G2: NR (P = NR)
| | | G2: 21.38 (6.21) | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS) | | G3: NR (P = NR)
| | | G3: 17.88 (4.36) | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR) | | Diff between G1 and G2 (P < 0.05)
| | | (P = NS) | | | | | | | | | | G2 > G1
| | | Duration of illness, yrs: mean (SD): | | | | | | | | | | Diff between G1+G2 and G3 (P = NS)
| | | G1: 5.13 (4.85) | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | G2: 3.13 (1.73) | | | | | | EDI, bulimia: | | 6-mo FU: | | 1 yr FU:
| | | G3: 7.75 (6.09) | | | | | | G1: NR (P = NR) | | M-R, Psychosexual functioning: | | BMI
| | | (P = NS) | | | | | | G2: NR (P = NR) | | G1: NR (P = NR) | | G1: NR (P = NR)
| | | Previous hospitalization, % yes: | | | | | | G3: NR (P = NR) | | G2: NR (P = NR) | | G2: NR (P = NR)
| | | G1: 50.0 | | | | | | Diff between groups (P = NS) | | G3: NR (P = NR) | | G3: NR (P = NR)
| | | G2: 12.5 | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups G1 and G2 | | Diff over time (P < 0.0001)
| | | G3: 37.5 | | | | | | | | (P < 0.02) | | Diff between groups
| | | (P = NS) | | | | | | | | G1 > G2 | | (P = NS)
| | | Binge eating % yes: | | | | | | | | Diff between groups G1+G2 and G3 | | Diff between groups in change over time (P = NR)
| | | G1: 25.0 | | | | | | | | (P = NS)
| | | G2: 50.0 | | | | | | | | Diff between groups in change over time (P = NR)
| | | G3: 12.5 | | | | | | M-R all scales: | | M-R mental state: | | M-R Menstual:
| | | (P = NS) | | | | | | G1: NR (P = NR) | | G1: NR (P = NR) | | G1: NR (P = NR)
| | | Vomiting % yes: | | | | | | G2: NR (P = NR) | | G2: NR (P = NR) | | G2: NR (P = NR)
| | | G1: 37.5 | | | | | | G3: NR (P = NR) | | G3: NR (P = NR) | | G3: NR (P = NR)
| | | G2: 75.0 | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS) | | Diff over time (P < 0.0002)
| | | G3: 37.5 | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR) | | Diff between groups (P = NS)
| | | (P = NS) | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | Laxative use, % yes: | | | | | | Preferred wt: | | 1 yr FU:
| | | G1: 0.0 | | | | | | G1: NR (P = NR) | | MOCI:
| | | G2: 37.5 | | | | | | G2: NR (P = NR) | | G1: NR (P = NR)
| | | G3: 25.0 | | | | | | G3: NR (P = NR) | | G2: NR (P = NR)
| | | (P = NS) | | | | | | Diff between groups (P = NS) | | G3: NR (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups (P = NS)
| | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 6 Mo FU: | | M-R Psychosexual:
| | | | | | | | | EDI, drive for thinness: | | G1: NR (P = NR)
| | | | | | | | | G1: NR (P = NR) | | G2: NR (P = NR)
| | | | | | | | | G2: NR (P = NR) | | G3: NR (P = NR)
| | | | | | | | | G3: NR (P = NR) | | Diff over time (P < 0.03)
| | | | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | | EDI, body dissatisfaction: | | M-R mental state:
| | | | | | | | | G1: NR (P = NR) | | G1: NR (P = NR)
| | | | | | | | | G2: NR (P = NR) | | G2: NR (P = NR)
| | | | | | | | | G3: NR (P = NR) | | G3: NR (P = NR)
| | | | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | | 1 Yr FU: | | M-R social:
| | | | | | | | | EDI, drive for thinness: | | G1: NR (P = NR)
| | | | | | | | | G1: NR (P = NR) | | G2: NR (P = NR)
| | | | | | | | | G2: NR (P = NR) | | G3: NR (P = NR)
| | | | | | | | | G3: NR (P = NR) | | Diff between G1 and G2 (P = NS)
| | | | | | | | | Diff over time (P < 0.05) | | Diff between G1+G2, G3
| | | | | | | | | Diff between G1 and G2 (P = NS) | | (P < 0.04)
| | | | | | | | | Diff between (G1+G2) vs G3 (P < 0.03) | | G3> G1 + G2
| | | | | | | | | G3 better than G1 or G2 | | Diff between groups in change over time
| | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over tme (P = NR)
| | | | | | | | | M-R Nutritional:
| | | | | | | | | G1: NR (P = NR)
| | | | | | | | | G2: NR (P = NR)
| | | | | | | | | G3: NR (P = NR)
| | | | | | | | | Diff over time (P < 0.0001)
| | | | | | | | | Diff between G1 and G2 (P = NS)
| | | | | | | | | Diff between G1+G2 and G3 (P < 0.04)
| | | | | | | | | G1 + G2 > G3
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Preferred wt:
| | | | | | | | | G1: NR (P = NR)
| | | | | | | | | G2: NR (P = NR)
| | | | | | | | | G3: NR (P = NR)
| | | | | | | | | Diff over time (P < 0.03)
| | | | | | | | | Diff between groups G1 and G2 (P < 0.04) G2 > G1
| | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | G1: Inpatient tx including wt restoration to the mean-matched popwt at age of AN onset, wkly individual family and group therapy, dietary counseling and occupational therapy. Inpatient tx followed by 12 sessions of outpatient tx involving patient and family. | ANOVAs and ANCOVAs for testing between group diffs at randomization; Paired t tests to test within and between group diffs at 1 and 2 yr FU. All values scores at one-yr FU. | Score: | Nutrition score (SE): | Nutrition score (SE): | Mental state (SE): | Mental State (SE): | Menstruation (SE): | Menstruation (SE):
Crisp, Norton et al., 1991 | Compare three different forms of tx and “no tx” for individuals with AN at one-yr FU. | G1: Inpatients (N = 30) | G1: 23.2 (4.9) | Diagnosed with AN (according to DMS-III R criteria), females, had AN for less than ten yrs and lived within outpatient reach of services (≤ 40 miles). | G2: 12 sessions (of 1–1.5 hours duration) of outpatient individual/family therapy over several mos. Decision about how much depended on needs of the patient. | Morgan and Russell scales used to evaluate nutritional status, menstrual status, and mental state | Fair | G1: 4.7 (0.4) | One yr FU: | G1: 5.6 (0.4) | One yr FU: | G1: 0.4 (0.2) | One-yr FU:
Companion article: | | G2: Outpatient individual and family psychotherapy and dietary counseling (N = 20) | G2: 21.2 (5.1) | Exclusion: | G3: 10 outpatient group therapy meetings with partient and 10 separate meetings for parents at mo intervals. | | Intent to treat: | G2: 5.3 (0.4) | G1: 7.3 (0.6) (P < 0.01) | G2: 5.4 (0.6) | G1: 6.1 (0.9) (P = NS) | G2: 0.2 (0.2) | G1: 4.5 (1.0) (P < 0.01)
Gowers, Norton et al., 1994 | | G3: Group psychotherapy (N = 20) | G3: 19.7 (2.6) | None reported | Dietary counseling and advice part of inpatient tx and offered on 4 occasions to the two outpatient conditions. | | Yes | G3: 5.0 (0.5) | G2: 8.1 (0.6) (P < 0.01) | G3: 5.8 (0.5) | G2: 7.3 (0.8) (P < 0.05) | G3: 0.8 (0.6) | G2: 4.4 (1.1) (P < 0.01)
Setting: | | G4: No further tx by research team (N = 20) | G4: 21.9 (4.5) | | G4: referred back to family doctor or local consultant with details of assessment along with advice on further management. In G4, 6 patients had no tx, 6 had inpatient tx, 5 had outpatient hospital tx, 3 had at least wkly contact with doc | | Blinding: | G4: 5.0 (0.3) | G3: 8.3 (0.7) (P < 0.01) | G4: 4.2 (0.6) | G3: 6.5 (0.8) (P = NS) | G4: 0.6 (0.4) | G3: 5.7 (1.5) (P < 0.05)
Inpatient and outpatient; St. George's Hospital; London, England, UK | | Enrollment: | (P = NR) | | No psychotropic drugs provided to any participants | | NR | | G4: 6.4 (0.7) (P = NS) | G1 vs G4 (P < 0.05) | G4: 5.5 (0.8) (P = NS) | | G4: 4.6 (0.3) (P < 0.05)
Enrollment period: | | - Patients comprised of successive referrals who fulfilled criteria; - 90 patients randomized; - Those who refused tx were defined as non-compliers (they were considered for FU analyses within their respective groups) | Sex: | | | | Adverse events: | | Diff between groups (P = NS) | Diff between groups all other comparisons (P = NS) | Diff between groups (P = NR) | | Diff between groups (P = NS)
1983-1987 | | Compliers: | Female: 100% | | | | One patient in outpatient tx group died as a result of her AN prior to tx beginning. | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NR)
| | G1: (N = 18) | Race/ethnicity: | | | | Funding: | Morgan-Russell Global score (SE): | Global Score (SE): | Mental state (SE): | Mental state (SD): | Wt, in kgs (SD): | Wt gain in kgs:
| | G2: (N = 18) | NR | | | | Marks and Spencer plc, St. George's Hospital Special Trustees and Worshipful Company of Grocers | G1: 3.5 (0.2) | One-yr FU: | G1: 5.6 (0.4) | 2-yr FU (SD)*: | G1: 40.8 (6.1) | G1: 9.6
| | G3: (N = 17) | Age at onset (SD): | | | | | G2: 3.9 (0.3) | G1: 5.5 (0.6) (P < 0.01) | G2: 5.4 (0.6) | G2: 7.2 (3.4) (P < 0.05) | G2: 40.3 (3.8) | G2: 9.0
| | G4: (N = 20) | G1: 19.8 (4.7) | | | | | G3: 3.8 (0.4) | G2: 6.4 (0.6) (P < 0.01) | G3: 5.8 (0.5) | G4: 5.5 (4.1) (P = NS) | G3: 40.2 (6.0) | G3: 10.1
| | | G2: 18.4 (3.9) | | | | | G4: 3.5 (0.3) | G3: 6.2 (0.7) (P < 0.05) | G4: 4.2 (0.6) | Diff between groups (P = NR) | G4: 41.0 (6.1) | G4: 3.2
| | | G3: 17.4 (1.9) | | | | | | G4: 5.6 (0.7) (P < 0.05) | G1 vs G4:(P ≤ 0.05) | Diff between groups in change over time (P = NS) | | Diff between groups (P = NR)
| | | G4: 17.4 (3.2) | | | | | | Diff between groups (P = NS) | Diff between groups all other comparisons (P = NS) | | | Diff between groups in change over time (P < 0.01)
| | | (P = NR) | | | | | | Diff between groups in change over time (P = NR) | | | | G4 < G1, G2, G3
| | | Duration of illness (SD): | | | | | | | | | Menstruation (SE): | Menstruation (SD):
| | | G1: 41.0 (30.17) | | | | | | | | | G1: 0.4 (0.2) | 2-yr FU (SD)*:
| | | G2: 33.4 (25.9) | | | | | | | | | G2: 0.2 (0.2) | G2: 6.1 (4.7) (P < 0.001)
| | | G3: 27.5 (25.8) | | | | | | | | | G3: 0.8 (0.6) | G4: 5.2 (5.7) (P < 0.001)
| | | G4: 53.5 (52.9) | | | | | | | | | G4: 0.6 (0.4) | Diff between groups (P = NS)
| | | (P = NR) | | | | | | | | | | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | G1 Focal psychoanalytic therapy which is a standardized form of time-limited psychoanalytic therapy. A doctor, social worker, and psychologist conducted therapy. Sessions lasted 50 m and occurred wkly for 1 yr. | Categorical data were analyzed using the Fisher exact probability test. ANCOVAs used to analyze continuous data, controlling for initial scores. T-tests used to compare pre and post scores. | Score: | | One-yr FU: | | One-yr FU: | | At one-yr FU:
Dare et al., 2001 | Compare two forms of individual psychodynamic tx's for adult AN with family therapy and controlled “routine” tx. | G1: Focal psychotherapy (N = 21) | G1: 26.7 (6.4) | DSM IV for AN, 18 or older at the time of entry into trial | G2 Family therapy, focuses on ED as problem of family life. Sessions were 1 hour to 1 hour 15 mins in duration and scheduled by negotiation between once a wk and once every 3 wks. Therapists saw patients, partner or spouse or parents for most of the sessions but individual contact was allowed at a max of once every 3 attendances. Same therapists as for G1. | | Fair | Morgan-Russell Assessment Schedule-A (nutritional status) (SD): | Morgan-Russell Assessment Schedule-A (nutritional status) (SD): | Morgan-Russell Assessment Schedule-C (Mental state) (SD): | Morgan-Russell Assessment Schedule-C (Mental state) (SD): | Morgan-Russell Assessment Schedule-B (Menstrual scale) (SD): | Morgan-Russell Assessment Schedule-B (Menstrual scale) (SD):
Setting: | | G2: Family therapy (N = 22) | G2: 26.6 (7.6) | Exclusion: | G3 Cognitive analytic therapy which combines elements of cognitive therapy and brief focused psychodynamic therapy. Sessions were 50 m and occurred wkly for the first 20 wks and then moly for 3 mos. Therapists were members of the ED team. | | Intent to treat: | Total: 2.4 (1.8) | Total: 4.3 (2.8) (P = 0.0001) | Total: 10.1 (2.5) | Total: 9.8 (3.0) (P = NS) | Total: 1.1 (2.8) | Total: 3.4 (4.7) (P = 0.0001)
Outpatient eating disorder program in Maudsley Hospital, UK | | G3: Cognitive-analytic therapy (N = 22) | G3: 27.2 (7.6) | If mental or physical state at assessment was considered so dangerous as to require hospitalization e.g., serious suicidal risk, extremely low wt (usually BMI < 12), hypoglycaemia, syncope or severe electrolyte disturbance (Potassium < 2.5 mMol/l; sodium < 130 mMol/l). | G4 ‘Routine’ tx which consisted of low-contact outpatient management with no specific psychotherapies used. Patients attended 30-minute sessions with a trainee psychiatrist. | | Yes | | Diff between groups (P = NS) | | Diff between groups (P = NS) | | Diff between groups (P = NS)
Enrollment period: NR | | G4: ‘Routine’ tx (N = 19) | G4: 24.3 (4.5) | | | | Blinding: | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | Enrollment: | (P = NS) | | | | NA | | | | | Baseline BMI (SD): | At one yr FU:
| | - Sequential referrals to the outpatient service were recruited for the study.; - Patients were assessed and given information about the four kinds of tx.; - Patients were interviewed with partners or family members following this and randomly allocated to one tx (total = 84); - Of the original 84 patients, 4 failed to attend the first tx session, 6 dropped out within the first 2 mos of tx and another 19 dropped out during the rest of tx.; - From the original sample, 61 came for FU interviews at one yr. Some information was obtained by phone for an additional 9 patients.; - 82 female; 2 male | Sex: Females | | | | Adverse events: | | | | | G1: 15.0 (1.6) | BMI (SD):
| | | G1: 100% | | | | 12 patients required hospitalization during the course of tx and 1 patient in G4 died. | | | | | G2: 15.2 (1.5) | Total: 16.5 (2.4) (P = 0.0001)
| | | G2: 91% | | | | Funding: | | | | | G3: 16.0 (1.7) | Diff between groups (P = NR)
| | | G3: 100% | | | | Leverhulme Foundation and Mental Health Research Fund | | | | | G4: 15.3 (1.6) | Diff between groups in change over time (P = 0.03)
| | | G4: 100% | | | | | | | | | Total: 15.4 (1.6) | Diff between G1 and G4 (P = 0.02)
| | | (P = NS) | | | | | | | | | | Diff between G2 and G4 (P = 0.05)
| | | Race/ethnicity: | | | | | | | | | | Diff between G3 and G4 (P = NS)
| | | NR | | | | | | | | | | One-yr FU no longer meeting criterion for AN (by DSM IV):
| | | Age at onset (SD): | | | | | | | | | | Recovered 1 yr (wt > 85% ABW, menstruation returned and no bulimic symptoms):
| | | G1: 18.8 (4.2) | | | | | | | | | | G1: 14%
| | | G2: 20.5 (7.5) | | | | | | | | | | G2: 14%
| | | G3: 19.9 (4.1) | | | | | | | | | | G3: 14%
| | | G4: 16.6 (4.1) | | | | | | | | | | G4: 0%
| | | (P = NS) | | | | | | | | | | Sig improved (wt > 85% ABW, no menstruation and/or occasional bulimic symptoms):
| | | Duration of illness (SD): | | | | | | | | | | G1: 19%
| | | G1: 6.7 (5.9) | | | | | | | | | | G2: 23%
| | | G2: 5.8 (4.9) | | | | | | | | | | G3: 14%
| | | G3: 6.7 (7.6) | | | | | | | | | | G4: 5%
| | | G4: 6.1 (5.0) | | | | | | | | | | Diff between groups; 3 specialty tx's vs. routine tx (P = 0.01)
| | | (P = NS) | | | | | | | | | | G2 vs G4 (P = 0.02)
| | | Bingeing daily: | | | | | | | | | | G1 vs G4 (P = 0.03)
| | | G1: 10% | | | | | | | | | | G3 vs G4 (P = NS)
| | | G2: 9% | | | | | | | | | | Diff between groups in change over time
| | | G3: 23% | | | | | | | | | | (P = NR)
| | | G4: 11%
| | | (P = NS)
| | | Bingeing > = wkly:
| | | G1: 5%
| | | G2: 5%
| | | G3: 5%
| | | G4: 26%
| | | (P = NS)
| | | Bingeing < wkly:
| | | G1: 10%
| | | G2: 9%
| | | G3: 0%
| | | G4: 0%
| | | (P = NS)
| | | Bingeing never:
| | | G1: 76%
| | | G2: 77%
| | | G3: 73%
| | | G4: 63%
| | | (P = NS)
| | | Vomiting daily:
| | | G1: 19%
| | | G2: 9%
| | | G3: 27%
| | | G4: 11%
| | | (P = NS)
| | | Vomiting < wkly:
| | | G1: 5%
| | | G2: 0%
| | | G3: 0%
| | | G4: 5%
| | | (P = NS)
| | | Vomiting never:
| | | G1: 62%
| | | G2: 68%
| | | G3: 55%
| | | G4: 63%
| | | (P = NS)
| | | Living arrangements:
| | | Family of origin:
| | | G1: 52%
| | | G2: 59%
| | | G3: 41%
| | | G4: 47%
| | | Spouse/cohabiting:
| | | G1: 14%
| | | G2: 27%
| | | G3: 32%
| | | G4: 21%
| | | Alone:
| | | G1: 33%
| | | G2: 14%
| | | G3: 27%
| | | G4: 32%
| | | Previous tx:
| | | Outpatient:
| | | G1: 48%
| | | G2: 27%
| | | G3: 41%
| | | G4: 26%
| | | Single inpatient:
| | | G1: 19%
| | | G2: 32%
| | | G3: 18%
| | | G4: 26%
| | | Repeat inpatient:
| | | G1: 5%
| | | G2: 23%
| | | G3: 18%
| | | G4: 32%
| | | Any tx:
| | | G1: 71%
| | | G2: 82%
| | | G3: 77%
| | | G4: 84%
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | G1: Inpatient tx including wt restoration to the mean-matched popwt at tage of AN onset, wkly individual family and group therapy, dietary counseling and occupational therapy. Inpatient tx followed by 12 sessions of outpatient tx involving the patient and the family. | ANOVAs and ANCOVAs for testing between group diffs at randomization; Paired t tests to test within and between group diffs at 1 and 2 yr FU. All values are scores at one-yr FU. | Score: | Nutrition (SE): | Nutrition (SE): | | | Wt, in kgs (SD): | Wt, kg (SD):
Gowers, Norton et al., 1994 | To compare long-term (i.e., 1 and 2-yr) outcomes of a combined individual-family therapy versus assessment-only control for treating symptoms of AN | G2: Outpatient individual and family psychotherapy and dietary counseling (N = 20) | G1: 23.2 (4.9) | Diagnosed with AN (according to DMS-III R criteria), females, had AN for less than ten yrs, and lived within outpatient reach of services (≤ 40 miles). | G2: 12 sessions (of 1–1.5 hours duration) of outpatient individual/family therapy over several mos. Decision about how much depended on needs of patient. | Morgan and Russell scales used to evaluate nutritional status, menstrual status, and mental state | Fair | G1: 4.7 (0.4) | 2-yr FU (SD): | | | G1: 39.5 (5.9) | 1-yr FU:
Companion article: | | G4: No further tx by research team Assessment-only (N = 20) | G2: 21.2 (5.1) | Exclusion: | G3: 10 outpatient group therapy meetings with patient and 10 separate meetings for parents at monthly intervals. | | Intent to treat: | G2: 5.3 (0.4) | G2: 9.2 (2.7) (P < 0.001) | | | G2: 41.0 (3.4) | G2: 48.76 (6.2) (P = NR)
Crisp, Norton et al., 1991 | | Enrollment: | G3: 19.7 (2.6) | None reported | Dietary counseling and advice part of inpatient tx and offered on 4 occasions to the two outpatient conditions. | | Yes | G3: 5.0 (0.5) | G4: 7.1 (3.1) (P < 0.01) | | | G3: 40.2 (6.4) | G4: 43.92 (8.0) (P = NR)
Setting: | | - Patients comprised of successive referrals who fulfilled criteria; - 90 patients randomized; - Those who refused tx were defined as non-compliers (they were considered for FU analyses within their respective groups) | G4: 21.9 (4.5) | | G4: Referred back to family doctor or local consultant with details of assessment along with advice on further management. In G4, 6 patients had no tx, 6 had inpatient tx, 5 had outpatient hospital tx, 3 had at least wkly contact with physician | | Blinding: | G4: 5.0 (0.3) | Diff between groups (P = NS) | | | G4: 41.0 (6.1) | Diff between groups (P < 0.05) G2 > G4
Inpatient and outpatient; St. George's Hospital; London, England, UK | | | (P = NR) | | No psychotropic drugs provided to any participants | | NR | | Diff between groups in change over time | | | | Diff between groups in change over time (P = NR)
Enrollment period: 1983-1987 | | | Sex: | | | | Adverse events: | | (P = NS) | | | | Wt, kg (SD):
| | | Female: 100% | | | | One patient in outpatient tx group died as a result of her AN prior to tx beginning. | | Abstinence/Remission by 2 yrs: | | | | 2-yr FU (SD):
| | | Race/ethnicity: | | | | Funding: | | G2: 20% | | | | G2: 52.51 (8.5) (P = NR); G4: 46.24 (8.6) (P = NR)
| | | NR | | | | Marks and Spencer plc, St. George's Hospital Special Trustees and Worshipful Company of Grocers | | G4: 10% | | | | Diff between groups (P < 0.05)
| | | Age at onset (SD): | | | | | | Diff between groups (P = NR) | | | | G2 > G4
| | | G1: 19.8 (4.7) | | | | | | | | | | Diff between groups in change
| | | G2: 18.4 (3.9) | | | | | | | | | | over time (P < 0.01) G2 > G4
| | | G3: 17.4 (1.9) | | | | | Morgan-Russell Global score (SE): | Morgan-Russell Global score (SD): | | | BMI (SD): | BMI (SD):
| | | G4: 17.4 (3.2) | | | | | G1: 3.5 (0.2) | Two-yr FU: | | | G2: 15.52 (1.4) | 1-yr FU:
| | | (P = NR) | | | | | G2: 3.9 (0.3) | G2: 7.5 (2.8) (P < 0.001) | | | G4: 15.84 (1.7) | G2: 18.97 (2.0) (P = NR)
| | | Duration of illness (SD): | | | | | G3: 3.8 (0.4) | G4: 6.2 (3.2) (P < 0.01) | | | | G4: 16.93 (2.8) (P = NR)
| | | G1: 41.0 (30.17) | | | | | G4: 3.5 (0.3) | Diff between groups (P = NR) | | | | Diff between groups (P < 0.05) G2 > G4
| | | G2: 33.4 (25.9) | | | | | | Diff between groups in change over time | | | | Diff between groups in change over time (P = NR)
| | | G3: 27.5 (25.8) | | | | | | (P = NS) | | | | 2-yr FU:
| | | G4: 53.5 (52.9) | | | | | | | | | | G2: 20.09 (2.8) (P = NR)
| | | (P = NR) | | | | | | | | | | G4: 17.83 (3.2) (P = NR)
| | | | | | | | | | | | | Diff between groups (P < 0.01) G2 > G4
| | | | | | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean: | Inclusion: | G1: 12 one hour sessions at one to two wkly intervals. Proportion of individual psychodynamic therapy and family therapy depended on clinical judgment, practicability and the willingness of the family to be involved. Patients seen by a dietitian for 4 15-minute interviews. | No description provided | Score: | | | Global clinical score: | One-yr FU: | | One yr FU:
Hall and Crisp, 1987 | Compare effect of outpatient brief individual and family psychotherapy or dietetic advice on wt and eating behavior among outpatients with AN at one yr FU. | G1: Psychotherapy group (N = 15) | G1: 19.55 | Diagnostic criteria for primary AN, aged 13–27, from social classes I-III, unmarried, wting less than 85% of matched population mean wt, had amenorrhea, had been ill for 6 – 72 mos and willing to attend outpatient tx. | G2: 12 one-hour sessions at wkly or fortnightly intervals. Family was seen with the participant on some occasions. All participants were seen by psychotherapist for four 15-minute interviews. | | Poor | NR | NR | G1: 5.7 | Global clinical score: | Wt, kgs: | Wt, kgs:
Setting: | | G2: Dietary advice group (N = 15) | G2: 19.57 | Exclusion: | | | Intent to treat: | | | G2: 6.3 | G1: 8.8 (P < 0.001) | G1: 41.00 | G1: 45.1 (P = NS)
Outpatient, UK | | Enrollment: | (P = NS) | None reported | | | Yes | | | | G2: 7.8 (P < 0.01) | G2: 39.54 | G2: 46.0 (P < 0.001)
Enrollment period: NR | | - 30 participants selected from consecutive referrals to one of the authors.; - Referrals initially screened by postal questionnaire and those meeting criteria were interviewed along with their families. | Social class: | | | | Blinding: | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | . | Group I and II: | | | | No | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | G1: 12 | | | | Adverse events:
| | | G2: 13 | | | | One patient in G1 deteriorated after tx ended and had to be hospitalized. 2 patients in G2 hospitalized.
| | | Group III: | | | | Funding:
| | | G1: 3 | | | | NR
| | | G2: 2
| | | (P = NS)
| | | Sex:
| | | Female: 100%
| | | Race/ethnicity:
| | | NR
| | | Height, cms:
| | | G1: 161.7
| | | G2: 162.3
| | | (P = NS)
| | | Age at onset of illness, mean:
| | | G1: 17.07
| | | G2: 17.53
| | | (P = NS)
| | | Age at onset of amenorrhea:
| | | G1: 17.77
| | | G2: 17.90
| | | (P = NS)
| | | Duration of illness, mos:
| | | G1: 29.7
| | | G2: 24.5
| | | (P = NS)
| | | Duration of amenorrhea, mos:
| | | G1: 27.5
| | | G2: 20.1
| | | (P = NS)
| | | Number having previous tx:
| | | G1: 10
| | | G2: 8
| | | (P = NS)
| | | Mean wt at onset of dieting (kg):
| | | G1: 52.50
| | | G2: 55.42
| | | (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Therapy in all 3 groups consisted of 20 hour-long manual-based sessions conducted over a min of 20 wks. | Pairwise comparisons among groups made using Mann-Whitney U test. Repeated measures ANOVA was used for secondary and tertiary outcome variables to measure change over time. Pairwise least significance tests used for FU comparisons. Logistic regression used to examine independence of tx effects. Non-parametric Kruskal-Wallis test used to compare global AN measure values. | Score: | EDE-Restraint (SD): | EDE-Restraint (SD): | Global assessment of functioning (SD): | Global assessment of functioning (SD): | Wt, in kgs: | Wt, in kgs:
McIntosh et al., 2005 | Examine effectiveness of CBT, interpersonal psychotherapy and control tx (nonspecific supportive clinical management) in treating AN on an outpatient basis. | G1: CBT (N = 19) | NR | Female; of age 17–40 yrs; current primary AN; included DSM IV wt criterion (BMI < 17.5) and more lenient wt criterion (BMI, 17.5–19.0); could be receiving stable dose of a psychotropic med with no change in AN symptoms | CBT: working on entrenched food restriction and avoidance patterns. | Created a 4 patient global AN rating scale: 4: meets full criteria for AN, min improved from baseline in wt, BMI, EDE but min improvement in EDI; 3: not full AN but having features of eating disorders, gained wt, min changes on EDE, considerable symptoms on EDI; 2: few features of eating disorders, “much improved”, 1: no sig features of ED, min symptoms on EDI and EDE | Fair | Total sample: 3.9 (1.3) | G1: 2.8 (1.7) | Total sample: 48.8 (5.6) | G1: 53.2 (9.5) | Total sample: 46.6 (3.9) | G1: 48.6 (5.5)
Setting: | | G2: Interpersonal psychotherapy (N = 21) | Sex: | Exclusion: | Interpersonal psychotherapy: based on IPT for depression and BN. | | Intent to treat: | | G2: 4.0 (1.5) | | G2: 51.1 (7.2) | | G2: 49.0 (8.5)
Outpatient setting in Christchurch, New Zealand | | G3: Nonspecific supportive clinical management (N = 16) | Female: 100% | BMI < 14.5; current severe major depression; psychoactive substance dependence; major medical or neurological illness; developmental learning disorder; cognitive impairment; bipolar I disorder; schizophrenia; chronic refractory course of AN | Nonspecific supportive clinical management: aimed at mimicking outpatient tx that could be offered in usual clinical practice and combined features of supportive psychotherapy and clinical management. Information provided about wt maintenance strategies, energy requirements and relearning to eat normally. | | Yes | | G3: 2.1 (1.7) | | G3: 60.7 (13.9) | | G3: 50.4 (7.3)
Enrollment period: NR | | Enrollment: | Race/ethnicity: | | | | Blinding: | | Diff between groups (P = NR) | | (P = NR) | | Diff between groups (P = NR)
| | Recruitment included referrals from health professionals, self-referrals and family referrals. 400 individuals inquired about study. 135 interviewed and 78 deemed eligible. 56 consented to participate and were randomly assigned to one of three tx's. 35 completed therapy (attending 15 of 20 sessions). | NR | | | | NA | | Diff between groups in change over time (P < 0.01) | | Change over time | | Diff between groups in change over time (P = NS)
| | | Comorbid dx of panic disorder: | | | | Adverse events: | | Diff between 2 groups in change over time (P < 0.05) | | Diff between groups in change over time (P < 0.02)
| | | G1: 26% | | | | Reported only for those who dropped out. Of these, 4 hospitalized (one died) for wt loss or medical complications of AN. | | G1 and G3 > G2 | | Diff between 2 groups in change over time (P < 0.05) G3 better than G1 or G2
| | | G2: 0 | | | | Funding: | EDE-Eating concerns (SD): | EDE-Eating concerns: | HDRS (SD): | HDRS (SD): | BMI (SD): | BMI (SD):
| | | G3: 19% | | | | Health Research Council of New Zealand | Total sample: 2.8 (1.3) | G1: 1.7 (1.7) | Total sample: 12.6 (6.9) | G1: 6.9 (7.8) | Total sample: 17.3 (1.1) | G1: 18.1 (1.9)
| | | Diff between groups (P < 0.05) | | | | | | G2: 2.5 (1.2) | | G2: 9.9 (7.3) | | G2: 18.1 (3.1)
| | | G1 > G2 and G3 | | | | | | G3: 1.8 (1.6) | | G3: 6.8 (7.1) | | G3: 18.8 (2.1)
| | | Comorbid dx of BN: | | | | | | Diff between groups (P = NR) | | (P = NR) | | Diff between groups (P = NR)
| | | G1: 63% | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | G2: 31% | | | | | EDE-wt concerns (SD): | EDE-wt concerns: | | | Body fat (SD): | Body fat (SD):
| | | G3: 19% | | | | | Total sample: 3.1 (1.7) | G1: 2.5 (1.2) | | | Total sample: 18.9% (3.4) | G1: 22.0% (5.3)
| | | Diff between groups (P < 0.05) | | | | | | G2: 1.8 (1.5) | | | | G2: 20.7% (6.6)
| | | G1 > G2 and G3 | | | | | | G3: 1.8 (1.5) | | | | G3: 22.1% (5.9)
| | | | | | | | | Diff between groups (P = NR) | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS) | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE-shape concerns (SD): | EDE-shape concerns:
| | | | | | | | Total sample: 3.8 (1.3) | G1: 2.7 (1.5)
| | | | | | | | | G2: 3.1 (1.7)
| | | | | | | | | G3: 2.6 (2.0)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDI-Drive for thinness (SD): | EDI-Drive for thinness:
| | | | | | | | Total sample: 11.7 (5.4) | G1: 7.9 (6.5)
| | | | | | | | | G2: 9.5 (5.6)
| | | | | | | | | G3: 6.8 (7.5)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDI-Bulimia (SD): | EDI-Bulimia:
| | | | | | | | Total sample: 3.1 (4.0) | G1: 1.5 (4.0)
| | | | | | | | | G2: 2.6 (3.2): G3: 1.8 (2.5)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDI-Body dissatisfaction (SD): | EDI-Body dissatisfaction:
| | | | | | | | Total sample: 7.7 (7.0) | G1: 5.8 (6.9)
| | | | | | | | | G2: 7.3 (7.6)
| | | | | | | | | G3: 7.7 (9.5)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Global outcome – rating of 1:
| | | | | | | | | G1: 5%
| | | | | | | | | G2: 0
| | | | | | | | | G3: 25%
| | | | | | | | | Global outcome – rating of 2:
| | | | | | | | | G1: 26%
| | | | | | | | | G2: 10%
| | | | | | | | | G3: 31%
| | | | | | | | | Global outcome – rating of 3:
| | | | | | | | | G1: 16%
| | | | | | | | | G2: 24%
| | | | | | | | | G3: 6%
| | | | | | | | | Global outcome – rating of 4 (P oor):
| | | | | | | | | G1: 53%
| | | | | | | | | G2: 67%
| | | | | | | | | G3: 38%
| | | | | | | | | (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G3 > G2 (P < 0.02)
| | | | | | | | | G3 vs G1 (P = NS)
| | | | | | | | | G2 vs G1 (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Both tx's consisted of 50 individual therapy sessions delivered over one yr. CBT and nutritional counseling based on manuals created by K. Pike. CBT focused on cognitive and behavioral features associated with maintenance of eating pathology and used a schema-based approach. Nutritional counseling was psychoeducational and supportive and focused on dietary analyses and balanced meal planning. Both txs conducted by PhD licensed, experienced psychologists. Participation terminated if subject's wt fell below BMI of 17.5 for > 10 days or if medical status compromised by exacerbation of AN pathology to the extent that inpatient care required or exacerbation of non-eating disorder pathology requiring alternative care. | T-tests conducted to compare baseline characteristics between of two groups. Kaplan Meier survival analyses done to compare time to relapse for the participants in the two tx groups. | Score: | NR | Time to relapse (sessions/wks): | Treatment logic: | NR | BMI (SD): | NR
Pike et al., 2003 | Assessed the efficacy of CBT vs. nutritional counseling in the posthospitalization tx of AN among outpatient adults. | G1: CBT (N = 18) | G1: 26.1 (6.2) | DSM IV dx of AN, successfully completed inpatient tx (defined as achievement of at least 90% IBW based on 1959 Metropolitan Life Insurance Tables) for a min of two wks, normalization of eating, resolution of acute medical problems and living within commuting distance of the hospital. | Participants monitored wkly. Allowed to continue with psychopharmacological tx started before study. | Relapsing not defined | Fair | | G1: 43.79 (2.9) | G1: 11.8 (3.0) | | G1: 16.0 (2.1
Setting: | | G2: Nutritional counseling (N = 15) | G2: 24.3 (6.9) | Exclusion: | | Full recovery defined using EDE as: good outcome, eating attitudes and wt concerns < 1 SD above mean of comprison group without ED, binge eating or purging had to be absent. | Intent to treat: | | G2: 27.21 (5.9) | G2: 10.61 (3.3) | | G2: 15.2 (1.5)
Outpatient, New York State Psychiatric Institute, USA | | Enrollment: | (P = NS) | NR | | | No | | Diff between groups (P = NR) | | | (P = NS)
Enrollment period: NR | | - 43 met initial eligibility criteria; - 33 randomly assigned to tx immediately before their first session which was scheduled within 1 wk of hospital discharge; - Random assignment based on an adaptive stratification procedure; - Dropout before session 10: G1: 0; G2: 3 | Range: 18–45 | | | | Blinding: | | Diff between groups in change over time (P < 0.004)
| | | Sex: | | | | NR | | Number of participants relapsing: | Treatment relevance:
| | | Female: 100% | | | | Adverse events: | | G1: 22% | G1: 10.6 (3.6)
| | | Race/ethnicity: | | | | Reasons for participants dropping out of tx or relapsing: wt loss, increased suicidality and in most cases, these were referred for inpatient tx or alternative tx. | | G2: 53% | G2: 10.0 (2.8)
| | | G1: NR% | | | | Funding: | | Diff between groups (P = NS)
| | | G2: NR% | | | | NIMH | | Overall tx failure (relapse + dropout): | Expectation of success:
| | | Age at illness onset (SD): | | | | | | G1: 22% (4 of 18) | G1: 10.2 (3.0)
| | | G1: 17.4 (5.2) | | | | | | G2: 73% (11 of 15) | G2: 11.6 (2.5)
| | | G2: 16.5 (3.1) | | | | | | Diff between groups (P < 0.003)
| | | (P = NS) | | | | | | Diff between groups in change over time (P = NR)
| | | Duration of illness (SD): | | | | | | Morgan-Russell criteria for “good outcome”:
| | | G1: 7.6 (5.9) | | | | | | G1: 44% (8 of 18)
| | | G2: 7.3 (5.8) | | | | | | G2: 7% (1 of 15)
| | | (P = NS) | | | | | | Diff between groups (P < 0.02)
| | | Previous hospitalizations (SD): | | | | | | Diff between groups in change over time (P = NR)
| | | G1: 1.8 (2.6) | | | | | | “Full Recovery”
| | | G2: 1.1 (1.2) | | | | | | G1: 17%
| | | (P = NS) | | | | | | G2: 0%
| | | Percent restricting type AN (N): | | | | | | Diff between groups (P = NS)
| | | G1: 56% (10) | | | | | | Diff between groups in change over time (P = NR)
| | | G2: 40% (6) | | | | | | Good vs fair/poor/other outcome
| | | (P = NS) | | | | | | Psychotropic med vs not
| | | | | | | | | G1(P < 0.04) On med superior to no med
| | | | | | | | | G2(P = 0.39)
| | | | | | | | | AN subtype
| | | | | | | | | G1:(P = NS)
| | | | | | | | | G2:(P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Initial bed rest, 3000 kcal/day, individual, milieu, and family therapy. | Chi square 2 tailed group comparisons | Score: | NR | NR | | | | Post tx:
Pillay and Crisp, 1981 | To investigate impact of a social skills program within a longer tx approach to AN. | G1: Social skills/social anxiety reduction (N = 11) | G1: 23.6 (8.2) | NR | G1: 12 sessions of social skills/social anxiety tx (approach behavior). | | Poor | | | | | Wt, kg, mean (SD): | Wt, kg, mean (SD)
Setting: | | G2: placebo nonspecific therapy (N = 12) | G2: 23.8 (7.8) | Exclusion: | G2: 12 sessions non-specific counseling | | Intent to treat: | | | | | G1: 41.0 (5.7) | G1: 54.4 (3.6) (P = NR)
Inpatient unit, London, UK | | Enrollment: | (P = NS) | NR | Intervention provided during 4 mo inpatient tx | | No | | | | | G2: 40.2 (7.5) | G2: 54.1 (5.2) (P = NR)
Enrollment period: NR | | - 33 patients enrolled; - 9 patients (8 from G2) dropped out and replaced by other patients.; - 1 excluded | Sex: | | Assessments: admission, post = target wt + 4 wks FU = 1 yr | | Blinding: | | | | | (P = NS) | Diff between groups (P = NR)
| | Completed | Female: 100% | | | | NA | | | | | | Diff between groups in change over time (P = NR)
| | G1: 11 | Race/ethnicity: | | | | Adverse events: | | | | | | % Wt increase, mean (SD)
| | G2: 12 | NR | | | | NR | | | | | | G1: 34.5 (15.5) (P = NR)
| | 1 yr FU | Married (N = 5): | | | | Funding: | | | | | | G2: 37.1 (18.6) (P = NR)
| | G1: 10 | G1: 2 | | | | St George's Medical Research Committee | | | | | | Diff between groups (P = NR)
| | G1: 12 | G2: 3 | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | (P = NS) | | | | | | | (CCEI, mean (SD): | CCEI, mean (SD): | | 1 Yr FU:
| | | Single (N = 18): | | | | | | | Anxiety | Anxiety | | Wt, kg, mean (SD)
| | | G1: 9 | | | | | | | G1: 11.1 (3.5 | G1: 8.9 (3.5) (P = 0.05) | | G1: 48.0 (7.1) (P = NR)
| | | G2: 9 | | | | | | | G2: 10.8 (3.6) | G2: 10.2 (4.6) (P = NS) | | G2: 47.4 (7.6) (P = NR)
| | | Social class, 1 or 2 (N = 9): | | | | | | | (P = NS) | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | G1: 4 | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | G2: 5 | | | | | | | Phobic Anxiety | Phobic Anxiety | | FU Wt as % MMPW, mean (SD):
| | | (P = NS) | | | | | | | G1: 5.2 (4.3) | G1: 4.4 (3.2) (P = NS) | | G1: 84.6 (11.7) (P = NR)
| | | 3/4/5 (N = 14): | | | | | | | G2: 4.3 (3.2) | G2: 5.3 (3.7) (P = NS) | | G2: 83.1 (10.9) (P = NR)
| | | G1: 7 | | | | | | | (P = NS) | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | G2: 7 | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | (P = NS) | | | | | | | Obsessionality | Obsessionality
| | | Ht, cm, mean (SD) (N = 162.6 [5.3]): | | | | | | | G1: 11.6 (2.1) | G1: 9.9 (1.5) (P = NS)
| | | G1: 162.7 (5.6) | | | | | | | G2: 8.8 (3.4) | G2: 7.9 (3.1) (P = NS)
| | | G2: 162.5 (5.1) | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | (P = NS) | | | | | | | | Diff between groups in change over time (P = NR)
| | | Vomiters (N = 10): | | | | | | | Depression | Depression
| | | G1: 6 | | | | | | | G1: 10.3 (4.2) | G1: 7.1 (3.8) (P = 0.01)
| | | G2: 4 | | | | | | | G2: 8.4 (3.9) | G2: 9.0 (4.0) (P = NS)
| | | (P = NS) | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | Wks as inpatient, mean (SD): | | | | | | | | Diff between groups in change over time (P = NR)
| | | G1: 17.4 (4.8) | | | | | | | Total Score | Total Score
| | | G2: 16.3 (4.7) | | | | | | | G1: 56.0 (15.8) | G1: 43.4 (14.7) (P = 0.01)
| | | (P = NS) | | | | | | | G2: 49.3 (14.1) | G2: 44.2 (16.4) (P = NS)
| | | WAIS equivalent score, mean (SD): | | | | | | | (P = NS) | (P = NR)
| | | G1: 106.0 (9.8) | | | | | | | | Diff between groups in change over time (P = NR)
| | | G2: 106.6 (14.0) | | | | | | | | 1 yr FU:
| | | (P = NS) | | | | | | | | CCEI, mean (SD)
| | | | | | | | | | | Anxiety
| | | | | | | | | | | G1: 9.4 (4.3) (P = 0.05)
| | | | | | | | | | | G2: 8.8 (3.9) (P = 0.01)
| | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | Phobia
| | | | | | | | | | | G1: 3.7 (3.3) (P = NS)
| | | | | | | | | | | G2: 4.3 (3.2) (P = NS)
| | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | Obsessionality
| | | | | | | | | | | G1: 10.3 (3.4) (P = NS)
| | | | | | | | | | | G2: 7.1 (2.8) (P = NS)
| | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | Depression
| | | | | | | | | | | G1: 7.5 (5.3) (P < 0.05)
| | | | | | | | | | | G2: 7.0 (4.0) (P < 0.04)
| | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | Total Score: FU
| | | | | | | | | | | G1: 44.2 (18.4) (P < 0.05)
| | | | | | | | | | | G2: 39.6 (14.4) (P < 0.01)
| | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Patients followed as usual, every 2–3 wks for 3 mo. G1: patients seen by occupational therapist who reviewed and adjusted level of exercise based on a graded protocol. Patients remained at each level of activity for at least 1 wk and progression to the next level determined by team. G2: patients encouraged to limit exercise. | Nonpaired two-tailed t-tests. | Score: | NR | NR | SF-36, mean (SD): | Change in SF-36, mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD): | Change in BMI, mean (SD):
Thien et al., 2000 | To determine whether an AN patient's quality of life is improved by being placed on a graded exercise program while not reducing gain of percent body fat or BMI. | G1: Graded Exercise (N = 8) | G1: 29.0 (4.4) | Age 17–45, DSM IV criteria of AN. | | | Poor | | | G1: 58.8 (13.9) | G1: 6.6 (7.0) (P = NR) | G1: 20.26 (1.8) | G1: 1.0 (1.3) (P = NR)
Setting: | | G2: Control (N = 8) | G2: 36.1 (7.9) | Exclusion: | | | Intent to treat: | | | G2: 53.3 (14.5) | G2: -12.0 (25.5) (P = NR) | G2: 17.2 (1.6) | G2: 0.8 (1.1) (P = NR)
St. Paul's Hospital EDs Outpatient clinic, Canada | | Enrollment: | Diff between groups (P = 0.05) | NR | | | No | | | (P = NS) | Diff between groups in change over time (P = NS) | (P = 0.02) | Diff between groups
Enrollment period: July 1997 | | - 16 enrolled; - 12 completed; - G1: 3/8 drop out; - G2: 1/8 drop out | % female: | | | | Blinding: | | | | | | (P = NS)
| | | G1: 100% | | | | NA | | | SF-36, RP, mean (SD): | Change in SF-36, RP, mean (SD): | %Body fat, mean (SD): | Change in %Body fat, mean (SD):
| | | G2: 86% | | | | Adverse events: | | | G1: 55.0 (37.1) | G1: 25.0 (35.4) (P = NR) | G1: 21.0 (2.9) | G1: 0.9 (2.1) (P = NR)
| | | Race/ethnicity: | | | | NA | | | G2: 50.0 (47.9) | G2:-10.7 (53.7) (P = NR) | G2: 16.7 (4.9) | G2: 0.5 (2.6) (P = NR)
| | | NR | | | | Funding: | | | (P = NS) | Diff between groups (P = NS) | (P = 0.05) | Diff between groups
| | | | | | | NR | | | | | | (P = NS)
| | | | | | | | | | SF-36, SF, mean (SD): | Change SF-36, SF, mean (SD):
| | | | | | | | | | G1: 72.5 (18.5) | G1: 5.0 (18.9) (P = NR)
| | | | | | | | | | G2: 62.5 (14.4) | G2: -19.6 (27.8) (P = NR)
| | | | | | | | | | (P = NS) | Diff between groups in change over time (P = 0.05)
| | | | | | | | | | SF-36, Vit, mean (SD): | Change in SF-36, Vit, mean (SD):
| | | | | | | | | | G1: 37.0 (28.2) | G1: 5.0 (25.7) (P = NR)
| | | | | | | | | | G2: 39.3 (24.4) | G2: -2.8 (32.3) (P = NR)
| | | | | | | | | | (P = NS) | Diff between groups in change over time (P = NS)
| | | | | | | | | | SF-36, sum of 3 scales, mean (SD): | Change in SF-36, sum of 3 scales, mean (SD):
| | | | | | | | | | G1: 54.8 (20.1) | G1: 11.7 (19.5) (P = NR)
| | | | | | | | | | G2: 50.6 (22.5) | G2: -11.0 (34.2) (P = NR)
| | | | | | | | | | (P = NS) | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD) (range): | Inclusion: | 20 wkly, 50 minutes sessions. | Mann-Whitney-U | Score: | | M-R, Nutrition, mean (SD) (range): | | Self rated improvement, mean (SD) (range): | Wt, kg, mean (SD) (range): | Wt, kg, mean (SD) (range):
Treasure et al., 1995 | To compare EBT and CAT for adult AN. | G1: EBT (N = 16) | G1: 25.3 (7) (18–39) | ICD-10 dx for AN, > 18 yrs old. | G1: monitor intake, goals to increase amt and range of food, wt/shape discussed, information re: nutrition and ED. G2: manual of Ryle (1990). Integrates psychodynamic factors with behavioral factors, transference, reformulate and interpret problems. | t-tests | Fair | | G1: 6.2 (4.0) (0–12) (P = NR) | | G1: 1.7 (0.9) (0–3) | G1: 42.2 (4) (34–50) | G1: 47 (7) (33–58) (P = NR)
Setting: | | G2: CAT (N = 14) | G2: 24.7 (5) (18–35) | Exclusion: | FU assessments at end of tx and 3 mo intervals up to 1 yr. | | Intent to treat: | | G2: 7.1 (2.8) (3–12) (P = NR) | | Diff between groups (P = NR) | G2: 42.9 (5) (34–51) | G2: 50 (6) (34–59) (P = NR)
Outpatients from the Eating Disorder Clinic at the Maudsley Clinic, London, UK | | Enrollment: | (P = NR) | Inpatient tx because of extreme, rapid wt loss with other severe sx. | | | Yes | | Diff between groups (P = NS) | | G2: 2.4 (0.5) (2–3) (P = NR) | | Diff between groups (P = NS)
Enrollment period: NR | | - 38 Assessed; - 32 met criteria; - 30 enrolled (1 refused, 1 lost more wt and was excluded); - completed 20 sessions:G1: N = 10 G2: N = 10 | Sex: | | | | Blinding: | | Diff between groups in change over time (P = NR) | | Diff between groups (P = 0.045) | | Diff between groups in change over time (P = NR)
| | | Female (N): 29 | | | | NA | | | | Diff between groups in change over time (P = NR)
| | | Race/ethnicity: | | | | Adverse events: | | M-R, avg score mean (SD) (range): | | | BMI, mean (SD) (range): | BMI mean (SD) (range):
| | | NR | | | | None reported | | G1: 6.4 (2.8) (1.8–11.7) | | | G1: 15.0 (1.0) (12.5–17.3) | G1: 17.4 (3.0) (12.3–20.7) (P = NR)
| | | Age onset, yrs, mean (SD) (range): | | | | Funding: | | G2: 7.3 (2.7) (3.3–11) | | | G2: 15.6 (2.1) (13–17.5) | G2: 18.5 (2.1) (14.1–21.8) (P = NR)
| | | G1: 20.8 (5) (12–34) | | | | Mental Health Foundation and the Society for Research into AN (aka: Eating Disorders Association) | | Diff between groups (P = NS) | | | | Diff between groups (P = NS)
| | | G2: 20.4 (5) (17–30) | | | | | | Diff between groups in change over time (P = NR) | | | | Diff between groups in change over time (P = NR)
| | | (P = NR) | | | | | | Bulimia Nervosa, N (%): | | | | Wt gain, kg, mean (SD) (range):
| | | % wt loss, mean (SD) (range): | | | | | | G1: 3 (19) (P = NR) | | | | G1: 6.7 (5.2) (-1 -14) (P = NR)
| | | G1: 28.9 (8) (20–24) | | | | | | G2: 2 (14) (P = NR) | | | | G2: 6.9 (4.3) (-8-16) (P = NR)
| | | G2: 25.5 (7) (18–42) | | | | | | Diff between groups (P = NS) | | | | Diff between groups (P = NS)
| | | (P = NR) | | | | | | Diff between groups in change over time (P = NR) | | | | Diff between groups in change over time (P = NR)
| | | Height, meters, mean (SD) (range): | | | | | | Good outcome (body wt maintained within 15% of ABW), N (%):
| | | G1: 1.67 (0.80) (1.55–1.3*) | | | | | | G1: 5 (31) (P = NR)
| | | G2: 1.66 (0.09) (1.5–1.85) | | | | | | G2: 6 (42) (P = NR)
| | | *error in paper* | | | | | | Diff between groups (P = NS)
| | | (P = NR) | | | | | | Diff between groups in change over time (P = NR)
| | | Duration amenorrhea, mos, mean (SD) (range): | | | | | | Intermediate outcome (body wt increased to within 15% of ABW with persistent amenorrhea), N (%):
| | | G1: 50.1 (60) (6–224) | | | | | | G1: 3 (19) (P = NR)
| | | G2: 63.1 (77) (6–264) | | | | | | G2: 5 (36) (P = NR)
| | | (P = NR) | | | | | | Diff between groups (P = NS)
| | | Premorbid wt, kg, mean (SD) (range): | | | | | | Diff between groups in change over time (P = NR)
| | | G1: 60.3 (10) (44–80) | | | | | | Poor outcome ( < 15% ABW), N (%):
| | | G2: 56.5 (8) (46–77) | | | | | | G1: 8 (50) (P = NR)
| | | (P = NR) | | | | | | G2: 3 (22) (P = NR)
| | | Bulimic episodes, N: | | | | | | Diff between groups (P = NS)
| | | G1: 4/16 | | | | | | Diff between groups in change over time (P = NR)
| | | G2: 5/14
| | | (P = NR)
| | | Vomiting, N:
| | | G1: 7/16
| | | G2: 7/14
| | | (P = NR)
| | | Laxatives, N:
| | | G1: 4/16
| | | G2: 5/14
| | | (P = NR)
| | | Previous hospitalizations, N:
| | | G1: 6/16
| | | G2: 3/14
| | | (P = NR)

Evidence Table 4. Behavioral intervention trials for adolescents with anorexia nervosa

| | | | | | | | Eating Related Measures | | Psychological/Psychiatric Measures | | Biomarkers
Study Description | Objective | Design | Patient Characteristics | Inclusion/Exclusion Criteria | Treatment | Statistical Methods | Quality | Baseline | Outcomes | Baseline | Outcomes | Baseline | Outcomes
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | One yr of CFT or SFT with assessments independent of the research team conducted at 3, 6, and 12 mos. Assessments included patient and family interviews and self-report questionnaires. Frequency of sessions dictated by clinical need and similar in both txs. Generally, families were seem wkly during the early stages of tx, gradually increasing to every 3 to 4 wks (mean number of sessions = 16.4 (8.9) for CFT and 15.5 (6.8) for SFT). CFT sessions lasted 1 hour; in SFT the individual and parental sessions each lasted 45 m. | ANCOVA, G1 vs. G2, taking duration of illness, previous tx, and wt and the T1 values of each measure as covariates. | Score: | Bulimic symptoms: | Change in bulimic symptoms: | Depression (SD): | Change in Depression (SD): | Lowest wt (kg): | Change in Wt (kg):
Eisler et al., 2000 | To compare the efficacy of two forms of outpatient family intervention for AN; conjoint family therapy (CFT) and separated family therapy (SFT). | G1: CFT (N = 19) | 15.5 yrs (1.6) | Adolescents, met DSM IV or ICD-10 criteria for AN | | | Good | > wkly (25%) | G1: - 2.2 (6.4) (P = NR) | 2.9 (3.2) | G1: - 5.6 (4.5) (P = NR) | 38.5 (6.2) | G1: + 6.4 (6.2) (P = NR)
Setting: | | G2: SFT (N = 21) | Sex: | Exclusion: | | | Intent to treat: | < wkly (22.5%) | G2: - 2.9 (4.5) (P = NR) | | G2: - 4.2 (5.7)(P = NR) | Current wt (kg): | G2: + 9.8 (6.7) (P = NR)
Outpatient at a postgraduate psychiatric teaching hospital in London, UK. Some patients may be inpatient at the hospital's eating disorder unit for some portion of the study | | Enrollment: | Female (N): 39 of 40 | None | | | Yes | Never (52.5%) | Change over time (P = 0.01) | | Change over time (P = 0.001) | 40.0 (6.4) | Change over time (P = 0.001)
Enrollment period: | | - 57 referrals to the hospital (14 did not meet dx criteria); - 40 enrolled; - 36 completed at least 3 mos of tx | Race/ethnicity: | | | | Blinding: | Bulimic symptoms (scale 0–12, 12 = normal with no symptoms) (SD): | Diff between groups (P = NR) | | Diff between groups (P = NR) | | Diff between groups (P = NR)
NR | | | NR | | | | NR | 7.7 (5.1) | Diff between groups in change over time(P = NS) | | Diff between groups in change over time (P = 0.02) | | Diff between groups in change over time (P = NS)
| | | Social class based on father's occupation: | | | | Adverse events: | | | | G1 better than G2
| | | I-II: Professional (65%) | | | | NR | EDI (SD): | Change in EDI: | Obsessionality (SD): | Change in Obsessionality (SD): | %ABW: | Change in %ABW:
| | | III-IV: Skilled (22%) | | | | Funding: | 56.2 (33.9) | G1: - 32.3 (25.9) (P = NR) | 8.3 (3.4) | G1: - 2.7 (2.8) (P = NR) | 74.3 (9.8) | G1: + 10.2 (11.3) (P = NR)
| | | VI-VIII: Unskilled (13%) | | | | Medical Research Council (UK) | | G2: - 21.8 (27.2) (P = NR) | | G2: - 1.2 (3.5) (P = NR) | | G2: + 15.0 (11.0) (P = NR)
| | | Family structure: | | | | | | Change over time (P = 0.001) | | Change over time (P = 0.001) | | Change over time (P = 0.001)
| | | Nuclear (70%) | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | Adoptive (5%) | | | | | | Diff between groups in change over time (P = 0.02) | | Diff between groups in change over time (P = 0.03) | | Diff between groups in change over time (P = NS)
| | | Single (10%) | | | | | | G1 better than G2 | | G1 better than G2
| | | Reconstituted (15%) | | | | | EAT (SD): | Change in EAT: | | | | Change in BMI:
| | | Age of AN onset (SD): | | | | | 47.7 (25.7) | G1: - 26.8 (20.8) (P = NR) | | | | G1: + 2.4 (2.5) (P = NR)
| | | 14.5 yrs (1.6) | | | | | | G2: - 29.2 (24.9) (P = NR) | | | | G2: + 3.6 (2.4) (P = NR)
| | | Duration of illness (mos): | | | | | | Change over time (P = 0.001) | | | | Change over time (P = 0.001)
| | | 12.9 (9.4) | | | | | | Diff between groups (P = NR) | | | | Diff between groups (P = NR)
| | | M-R Scales (SD): | | | | | | Diff between groups in change over time (P = NS) | | | | Diff between groups in change over time (P = NS)
| | | A (Nutritional): 3.3 (1.8) | | | | | | | SMFQ (SD): | Change in SMFQ (SD):
| | | B (Menstrual): 1.8 (3.0) | | | | | | | 26.5 (13.3) | G1: 16.5 (16.5) (P = NR)
| | | C (Mental State): 7.1 (2.0) | | | | | | | | G2: 8.0 (11.5) (P = NR)
| | | D (Psychosexual): 7.0 (3.7) | | | | | | | | Change over time (P = 0.001)
| | | E (Psychosocial): 8.0 (2.9) | | | | | | | | Diff between groups (P = NR)
| | | Avg: 5.5 (1.7) | | | | | | | | Diff between groups in change over time (P = 0.01)
| | | | | | | | | | | G1 better than G2
| | | | | | | | | | MOCI (SD): | Change in MOCI (SD):
| | | | | | | | | | 6.2 (3.6) | G1: - 2.8 (3.8) (P = NR)
| | | | | | | | | | | G2: - 2.4 (4.0) (P = NR)
| | | | | | | | | | | Change over time (P = 0.001)
| | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Upon reaching a near-healthy body wt and being discharged from inpatient tx, patients randomly assigned to conditions which were delivered on outpatient basis for one yr. Tx lasted 1 hour at least fortnightly for first 3 mos, then once every three wks for a total of 1 yr from date of discharge. | For subjects missing 5-yr data, 3-yr data substituted in analyses | Score: | | Category of outcome at 5 years, N: | | M-R scales: mental state at 5 years, mean (SD): | | Wt, % ABW at 5 years, mean (SD):
Eisler et al., 1997 | To determine the long term benefit of family versus individual therapy in AN after 5 yrs. | G1: Family Therapy (N = 41) | 17.9 (6.4) | AN: DSM III criteria; self-induced wt loss through avoidance of fattening foods, excessive exercise, and self-induced vomiting or purging (but did not follow binge eating); idea that fatness is dreadful state; specific endocrine disorder (amenorrhea or in males sexual interest/potency lost). | G1: Family therapy: Included all members of the household. Tasks: family cooperation, organization (communication, rules), interventions (management, cooperation, support, consistency) | Chi square, Fisher exact probability test, student t tests | Fair | | Subgroup 1: | | Subgroup 1: | | Subgroup 1:
Companion article: | | G2: Individual Therapy (N = 39) | (P = NS) | BN: DSM III-R preoccupation with food and episodes of gross overeating; counteract fattening effects of food by vomiting, purging, or starvation; psychopathology similar to AN; hx of previous overt or minor episode of AN. | G2: Nonspecific form of individual therapy: supportive, educational, problem-centered | Eating outcome categories: | Intent to treat: | | Total Subgroup: | | G1: 12.0 (0.0) | | G1: 103.4 (13.2)
Russell et al., 1987 | | Enrollment: | Age at end of trial, mean (SD): | Exclusion: | Antidepressant drug use allowed for both groups. | Good: body wt maintained within 15% of the ABW and menstrual cycles regular. | Yes | | Good: 13 | | G2: 11.5 (1.4) | | G2: 94.4 (16.8)
Setting: | | Of 80 original participants | 21.8 (7.1) | NR | Amount of sessions, mean (SD): | Intermediate: body wt risen to within 15% of ABW but amenorrhea persists. | Blinding: | | Intermediate: 2 | | Diff between groups (P = NS) | | Diff between groups (P = NS)
Output tx: Maudsley Hospital, London, UK | | - Followed at 3 yrs: N = 77; - Followed at 5 yrs: N = 73 | (P = NS) | | G1: 10.5 (8.9) | Poor: body wt < 15% below ABW or bulimic sx have developed | NA | | Poor: 6 | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
Enrollment period: | | | Duration of illness, y, mean (SD): | | G2: 15.9 (8.5) | | Adverse events: | | G1: Good: 9 | | Subgroup 2: | | Subgroup 2:
NR | | | 3.8 (3.1) | | Diff between groups (P < 0.01) | | Deaths, N: 3 | | Intermediate: 0 | | G1:9.1 (3.8) | | G1: 86.9 (11.9)
| | | Diff between groups (P = NS) | | | | Funding: | | Poor: 1 | | G2: 9.5 (2.1) | | G2: 95.7 (11.5)
| | | Wt on admission, % ABW, mean (SD): | | | | Medical Research Council, UK | | G2: Good: 4 | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | 69.6 (13.0) | | | | | | Intermediate: 2 | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | (P = NS) | | | | | | Poor: 5 | | Subgroup 3: | | Subgroup 3:
| | | Wt on discharge, % ABW, mean (SD): | | | | | | Diff between groups Good vs Intermediate + Poor (P < 0.02) G1 > G2 | | G1: 9.7 (2.1) | | G1: 93.7 (18.0)
| | | 89.5 (7.1) | | | | | | Diff between groups in change over time (P = NR) | | G2: 12.0 (0.0) | | G2: 97.5 (9.0)
| | | (P = NS) | | | | | | Subgroup 2: | | Diff between groups (P ≤ 0.05) G2 > G1 | | Diff between groups (P = NS)
| | | Duration of index hospital stay, wk, mean: | | | | | | Total Subgroup: Good: 4 | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | 10.4 | | | | | | Intermediate: 5 | | Subgroup 4: | | Subgroup 4:
| | | G1: 8.8 | | | | | | Poor: 10 | | G1: 8.0 (3.0) | | G1: 93.4 (8.9)
| | | G2: 12.1* | | | | | | G1: Good: 3 | | G2: 10.2 (2.1) | | G2: 98.9 (8.8)
| | | (P = NR) | | | | | | Intermediate: 1 | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | Subgroup 1: | | | | | | Poor: 6 | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | G1: 8.6 | | | | | | G2: Good: 1
| | | G2: 11.8 | | | | | | Intermediate: 4
| | | Diff between groups (P < 0.05) | | | | | | Poor: 4
| | | Subgroup 2: | | | | | | Diff between groups (P = NS)
| | | G1: 8.2 | | | | | | Diff between groups in change over time (P = NR)
| | | G2: 13.0 | | | | | | Subgroup 3:
| | | Diff between groups (P < 0.02) | | | | | | Total subgroup: Good: 6
| | | Previous admissions, N, mean: 1.5 | | | | | | Intermediate: 4
| | | Diff between groups (P = NS) | | | | | | Poor: 4
| | | Sex, N: | | | | | | G1: Good: 2
| | | Male: 7 | | | | | | Intermediate: 2
| | | Female: 73 | | | | | | Poor: 3
| | | Diff between groups (P = NS) | | | | | | G2: Good: 4
| | | Race/ethnicity: | | | | | | Intermediate: 2
| | | NR | | | | | | Poor: 1
| | | Marital status, N: | | | | | | Diff between groups (P = NS)
| | | Single: 69 | | | | | | Diff between groups in change over time (P = NR)
| | | Married: 8 | | | | | | Subgroup 4: | | M-R scales: Psychosexual adjustment at 5 years mean (SD): | | M-R scales: menstrual functioning at 5 years, mean (SD):
| | | Separated/divorced: 3 | | | | | | Total subgroup: Good: 3 | | Subgroup 1: | | Subgroup 1:
| | | (P = NS) | | | | | | Intermediate: 6 | | G1: 10.5 (2.1) | | G1: 12.0 (0.0)
| | | | | | | | | Poor: 10 | | G2: 9.2 (2.2) | | G2: 7.0 (5.1)
| | | | | | | | | G1: Good: 0 | | Diff between groups (P = NS) | | Diff between groups (P ≤ 0.05)
| | | | | | | | | Intermediate: 4 | | Diff between groups in change over time (P = NR) | | G1 > G2
| | | | | | | | | Poor: 5 | | Subgroup 2: | | Diff between groups in change over time (P = NR)
| | | | | | | | | G2: Good: 3 | | G1: 8.5 (3.0) | | Subgroup 2:
| | | | | | | | | Intermediate: 2 | | G2: 8.1 (3.0) | | G1: 3.4 (5.9)
| | | | | | | | | Poor: 5 | | Diff between groups (P = NS) | | G2: 4.5 (5.0) diff between groups (P = NS)
| | | | | | | | | Diff between groups (P = NS) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Subgroup 3: | | Subgroup 3:
| | | | | | | | | | | G1: 6.0 (4.3) | | G1: 7.4 (5.4)
| | | | | | | | | | | G2: 10.1 (1.4) | | G2: 11.3 (1.6)
| | | | | | | | | | | Diff between groups (P ≤ 0.05) G2 better than G1. | | Diff between groups (P = NS)
| | | | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | Subgroup 4: | | Subgroup 4:
| | | | | | | | | | | G1: 8.5 (4.1) | | G1: 8.5 (5.4)
| | | | | | | | | | | G2: 9.0 (3.3) | | G2: 7.5 (5.4)
| | | | | | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | | M-R scales: nutritional status at 5 years, mean (SD): | | M-R scales: social adjustment mean at 5 years (SD):
| | | | | | | | | Subgroup 1: | | Subgroup 1:
| | | | | | | | | G1: 9.4 (1.8) | | G1: 11.1 (1.2)
| | | | | | | | | G2: 8.7 (2.8) | | G2: 10.2 (1.6)
| | | | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | | Subgroup 2: | | Subgroup 2:
| | | | | | | | | G1: 7.4 (4.4) | | G1: 9.6 (2.1)
| | | | | | | | | G2: 7.2 (3.3) | | G2: 8.7 (2.9)
| | | | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | | Subgroup 3: | | Subgroup 3:
| | | | | | | | | G1: 7.6 (4.8) | | G1: 8.8 (3.0)
| | | | | | | | | G2: 9.2 (2.0) | | G2: 10.5 (1.6)
| | | | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | | Subgroup 4: | | Subgroup 4:
| | | | | | | | | G1: 6.2 (2.5) | | G1: 7.0 (2.5)
| | | | | | | | | G2: 7.4 (4.2) | | G2: 9.5 (3.0)
| | | | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | M-R scales: avg outcome at 5years, mean (SD): years, mean (SD):
| | | | | | | | | | | Subgroup 1:
| | | | | | | | | | | G1: 11.0 (0.4)
| | | | | | | | | | | G2: 9.3 (2.1)
| | | | | | | | | | | Diff between groups (P ≤ 0.05)
| | | | | | | | | | | G1 better than G2
| | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | Subgroup 2:
| | | | | | | | | | | G1: 7.6 (3.0)
| | | | | | | | | | | G2: 7.6 (2.5)
| | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | Subgroup 3:
| | | | | | | | | | | G1: 7.8 (2.8)
| | | | | | | | | | | G2: 10.6 (1.0)
| | | | | | | | | | | Diff between groups (P ≤ 0.05)
| | | | | | | | | | | G2 better than G1
| | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | Subgroup 4:
| | | | | | | | | | | G1: 7.6 (2.7)
| | | | | | | | | | | G2: 8.5 (2.8)
| | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | G1: 8 sessions of family therapy (every two wks). Sessions were 45 m, attended by patients, parents, and siblings. Therapists were social workers and 1 psychiatrist. | Two-way multivariate MANOVA and ANOVA repeated measures. | Score: | EDI measures, mean (SD): | EDI measures, mean (SD): | CDI, mean (SD): | CDI, mean (SD): | Wt:
Geist et al., 2000 | Comparison of family therapy and family group psychoeducation for adolescent inpatients (who later became outpatients) with AN | G1: Family Therapy (N = 12) | G1: 14.3 (1.5) | Admitted for inpatient tx, current wt < 90% of IBW (modification of DSM IV AN dx requiring < 85%) and self-imposed food restriction indicating onset or maintenance of low wt. | G2: 8 sessions of family psychoeducation every 2 wks. Classes were 90 m, led by a dietitian, occupational therapist and psychiatric nurse. First 45 m, patients and parents together. Second 45 minutes separate. Both txs lasted 4 mo. | Patients completed post tx assessment after 16 wks (T2) using same measures as beginning of tx (T1). | Fair | Drive for thinness: | Drive for thinness: | G1: 11.8 (6.6) | G1: 12.2 (7.4) (P = NR) | G1: 41.1 kg (7.0)
Setting: | | G2: Family Group Psychoeducation (N = 13) | G2: 14.9 (1.7) | Exclusion: | All participants received standard medical and psychosocial tx. Once patients medically stable and met target wts, discharged to outpatient unit. Remainder of sessions carried out on outpatient basis. | | Intent to treat: | G1: 11.1 (5.8) | G1: 12.3 (7.5) (P = NR) | G2: 14.0 (4.7) | G2: 15.4 (4.9) (P = NR) | G2: 41.1 kg (6.3)
Inpatient/Outpatient Adolescent Eating Disorders Unit, The Hospital for Sick Children, Toronto, Canada | | Enrollment: | (P = NS) | < 12 and > 17.4 yrs of age, male, chronic medical condition, immediate suicide risk, presented with psychotic features, unavailable over the study period, receiving individual or family therapy in the community or could not communicate in English. | | | Yes | G2: 13.7 (6.2) | G2: 13.3 (7.6) (P = NR) | (P = NR) | Diff between groups (P = NS) | (P = NS)
Enrollment period: | | - 120 assessed and admitted to inpatient program; - 61 met study criteria; - 36 refused to participate; - 25 enrolled and completed | Sex: | | | | Blinding: | (P = NR) | Diff between groups (P = NS) | | Diff between groups in change over time (P = NS)
2.5 yrs (dates not reported) | | | Female: 100% | | | | NR | Body Dissatisfaction: | Diff between groups in change over time (P = NS)
| | | Race/ethnicity: | | | | Adverse events: | G1: 9.1 (6.6) | Body Dissatisfaction:
| | | NR | | | | 5 participants readmitted to inpatient program during the study and another 6 later readmitted after the study was completed. | G2: 11.0 (5.0) | G1: 10.6 (9.2) (P = NR)
| | | Dx: | | | | Funding: | (P = NR) | G2: 12.2 (6.1) (P = NR)
| | | RAN (excluding amenorrhea criteria) (N = 19) | | | | Physician Services Inc. | Bulimia: | Diff between groups (P = NS)
| | | EDNOS (restricting) (N = 3) | | | | | G1: 1.2 (1.3) | Diff between groups in change over time (P = NS)
| | | Study criterion only (N = 3) | | | | | G2: 1.9 (1.6) | Bulimia:
| | | | | | | | (P = NR) | G1: 1.2 (2.0) (P = NR)
| | | | | | | | | G2: 2.5 (2.6); (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | | BSI, global severity, mean (SD): | BSI, global severity, mean (SD): | IBW, %: | IBW, %:
| | | | | | | | | | Patient: | Patient | G1: 77.7% | G1: 91.4% (P = NR)
| | | | | | | | | | G1: 1.3 (0.6) | G1: 1.2 (0.7) (P = NR) | G2: 77.2% | G2: 96.3% (P = NR)
| | | | | | | | | | G2: 1.4 (0.9) | G2: 1.2 (0.6) (P = NR) | (P = NR) | Change over time (P < 0.0001)
| | | | | | | | | | (P = NR) | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | | Mother: | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | | | | G1: 0.7 (0.8) | Mother:
| | | | | | | | | | G2: 0.6 (0.5) | G1: 0.6 (0.5) (P = NR)
| | | | | | | | | | (P = NR) | G2: 0.6 (0.5) (P = NR)
| | | | | | | | | | Father: | Diff between groups (P = NS)
| | | | | | | | | | G1: 0.7 (0.7) | Diff between groups in change over time (P = NS)
| | | | | | | | | | G2: 0.4 (0.3) | Father:
| | | | | | | | | | (P = NR) | G1: 0.4 (0.4) (P = NR)
| | | | | | | | | | | G2: 0.3 (0.2) (P = NR)
| | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | | FAM III, mean (SD): | FAM III, mean (SD):
| | | | | | | | | | G1: 48.3 (7.3) | G1: 52.2 (8.5) (P = NR)
| | | | | | | | | | G2: 50.9 (10.8) | G2: 55.8 (7.7) (P = NR)
| | | | | | | | | | (P = NR) | Change over time (P = 0.02)
| | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups (N = 18): | Age, mean (SD): | Inclusion: | Both txs included wkly sessions, gradually spread out as they progressed to 32 wks; both txs first address wt gain, then include family in tx of ED-related issues | Comparisons made between group and within group; further methodological details: NR | Score: | EAT scores, mean (SD): | End-of-tx (32 wks): | | | Wt (% ABW), mean (SD): | End-of-tx (32 wks):
le Grange et al., 1992 | To assess, in adolescents with AN, the efficacy of conjoint family therapy in which the whole family is seen together versus separate session, family counseling in which parents and adolescents seen separately. | G1: Family Therapy (conjoint) (N = NR) | 15.33 (1.81) | Meet DSM III-R criteria for AN; < 18 yrs old; duration of illness < 3 yrs | G1: whole family in all tx sessions; | Assessments at baseline, 16 wks, and 32 wks, including patient's biological and psychological variables and family interaction variables. | Poor | G1: 36.9 (27.6) | EAT scores, mean (SD): | | | G1: 75.9% (8.8) | Wt (% ABW), mean (SD):
Setting: | | G2: Family Counseling (separate) (N = NR) | | Exclusion: | G2: separate sessions between parents and therapist, and patient and therapist. | | Intent to treat: | G2: 35.3 (22.8) | G1: 16.6 (12.1) (P = 0.01) | | | G2: 80.5% (5.3) | G1: 89.1% (13.5) (P = 0.006)
Outpatient ED clinic; UK | | Enrollment: | Range: 12–17 | Medical risk or risk of suicide requiring hospitalization; comorbid major psychiatric disorder | Avg # of tx sessions, 6 mos, mean (SD): | | No | (P = NS) | G2: 15.6 (9.5) (P = 0.01) | | | (P value is not reported because inconsistent between table and text) | G2: 100.4% (9.1) (P = 0.0001)
Enrollment period: | | 18 consecutively referred from Department of Children and Adolescents, Bethlem Royal and Maudsley Hospital, randomized and enrolled | Sex (N): | | G1: 8.6 (4.12) | | Blinding: | | Diff between groups (P = NR) | | | | (P = NR)
NR | | Duration of Illness: | Female: 16 | | G2: 9.3 (4.37) | | No | | Diff between group in change over time (P = NS) | | | | Diff between group in change over time (P = NS)
| | < 3 yrs | Male: 2 | | (P = NR) | | Adverse events: | M-R scores, avg outcome score, mean (SD): | M-R scores, mean (SD):
| | | Race/ethnicity: | | | | NR | G1: 3.9 (1.7) | G1: 7.3 (2.0) (P = 0.01)
| | | NR | | | | Funding: | G2: 4.8 (1.5) | G2: 8.8 (1.4) (P = 0.01)
| | | Duration of Illness, mean mo (SD): | | | | NR | (P = NS) | Diff between groups (P = NR)
| | | 13.7 (8.38) | | | | | | Diff between group in change over time (P = NS)
| | | DSM III-R for BN:
| | | G1: 1
| | | G2: 3
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Randomized to either a short-term (10 sessions over 6 mos) or long-term tx (20 sessions over 12 mos). ED variables were evaluated at 6 mos and 1 yr using the EDE and YBC-ED. | Repeated measures for each subject; Effect sizes are reported using the mean diff between groups divided by the pooled within-group SD; In a post hoc analysis, linear regression model was employed (using 1 yr FU data as the dependent measure and controlling for baseline values.) | Score: | All comparisons refer to intent-to-treat outcomes: | | | | BMI, kg/m^2^;, mean (SD): | BMI, kg/m^2^;, mean (SD):
Lock et al., 2005 | To determine the optimal length of family tx for adolescents with AN. | G1: Long-term tx (N = 42) | G1: 15.2 (1.7) | DSM IV criteria for AN, though some partially wt restored participants entered; for postmenarchal females, those who had missed a min of one menstrual period instead of the three required by DSM IV criteria. | Manual-based txs (Dare and Eisler, 1997) conducted on an outpatient basis. In G2, sessions held wkly for 7 wks, then moly for 2 mos, and a final session at the 6 mos. In G1, sessions first held wkly for 7 wks, then biwkly through session 13, and finally, seven sessions were moly until the 1yr mark. | | Good | EDE-Eating Concerns, mean (SD): | EDE-Eating Concerns, mean (SD) | | | G1: 17.3 (1.5) | 6 mos:
Setting: | | G2: Short-term tx (N = 44) | G2: 15.2 (1.6) | Exclusion: | All questionnaires were completed by the participants at home. | | Intent to treat: | G1: 1.04 (1.33) | 6mos: | | | G2: 17.0 (1.3) | G1:19.0 (1.8) (P = NS)
Outpatient clinic for child and adolescent eating disorders, Stanford University School of Medicine, Stanford, CA, USA. | | Enrollment: | (P = NS) | Severe physical health problems likely to affect wt or psychiatric illnesses that would interfere with tx (e.g., psychosis); those who had failed family tx using the model employed in the study; use of psychotherapy in addition to that offered in the study protocol; (Psychotropic meds used to treat common comorbid psychiatric illnesses allowed.) | | | Yes | G2: 1.35 (1.13) | G1: 0.75 (1.00) (P = NS) | | | (P = NS) | G2:19.0 (2.3) (P = NS)
Enrollment period: | | - 241 assessed for eligibility; - 155 excluded (100 not meeting study criteria; 55 refusing participation); - 86 (61%) randomized; - G1: 3 lost to FU, 7 discontinued intervention; G2: 5 lost to FU, 2 discontinued intervention | Sex, N (%): | | | | Blinding: | (P = NS) | G2: 0.86 (1.01) (P = NS) | | | | Diff between groups (P = NS)
September 1999 to April 2002 | | | Female | | | | Yes | | Diff between groups (P = NS) | | | | Diff between groups in change over time (P = NS)
| | | G1: 38 (91%) | | | | Adverse events: | | Diff between groups in change over time (P = NS) | | | | 1 yr:
| | | G2: 39 (89%) | | | | Brief hospitalization for medical instability was needed for participants in both groups (22% overall; G1: 21%, G2: 10%); One participant dropped out due to need for other psychiatric tx. | | 1 yr: | | | | G1: 19.5 (2.1) (P = NS)
| | | Race/ethnicity, N (%): | | | | Funding: | | G1: 0.52 (0.83) (P = NS) | | | | G2: 19.5 (2.2) (P = NS)
| | | Asian | | | | NIH Career Development Award | | G2: 0.71 (0.92) (P = NS) | | | | Diff between groups (P = NS)
| | | G1: 2 (5%) | | | | | | Diff between groups (P = NS) | | | | Diff between groups in change over time (P = NS)
| | | G2: 6 (14%) | | | | | | Diff between groups in change over time (P = NS)
| | | White | | | | | EDE-Restraint, mean (SD): | EDE-Restraint, mean (SD) | | | Wt (kg), mean (SD): | Wt (kg), mean (SD):
| | | G1: 32 (76%) | | | | | G1: 2.64 (1.96) | 6mos: | | | G1: 46.7 (7.2) | 6mos:
| | | G2: 32 (73%) | | | | | G2: 2.76 (1.97) | G1: 1.64 (1.70) (P = NS) | | | G2: 44.6 (5.5) | G1: 51.4 (7.5) (P = NS)
| | | Hispanic | | | | | (P = NS) | G2: 1.84 (1.77) (P = NS) | | | (P = NS) | G2: 50.6 (8.1) (P = NS)
| | | G1: 6 (14%) | | | | | | Diff between groups (P = NS) | | | | Diff between groups (P = NS)
| | | G2: 4 (9%) | | | | | | Diff between groups in change over time (P = NS) | | | | Diff between groups in change over time (P = NS)
| | | Native American | | | | | | 1 yr: | | | | 1 yr:
| | | G1: 0 (0%) | | | | | | G1: 1.42 (1.63) (P = NS) | | | | G1: 53.2 (8.0)
| | | G2: 1 (2%) | | | | | | G2: 1.62 (1.80) (P = NS) | | | | G2: 52.0 (7.6)
| | | Other | | | | | | Diff between groups (P = NS) | | | | Diff between groups (P = NS)
| | | G1: 2 (5%) | | | | | | Diff between groups in change over time (P = NS) | | | | Diff between groups in change over time (P = NS)
| | | G2: 1 (2%) | | | | | EDE-Shape Concerns, mean (SD): | EDE-Shape Concerns, mean (SD)
| | | (P = NS) | | | | | G1: 2.41 (1.67) | 6mos:
| | | Duration of Eating Problem, mos (SD): | | | | | G2: 2.61 (1.73) | G1: 1.96 (1.55) (P = NS)
| | | G1: 12.0 (9.9) | | | | | (P = NS) | G2: 2.25 (1.63) (P = NS)
| | | G2: 11.3 (10.4) | | | | | | Diff between groups (P = NS)
| | | (P = NS) | | | | | | Diff between groups in change over time (P = NS)
| | | Hospitalization before tx, N (%): | | | | | | 1 yr:
| | | G1: 14 (34%) | | | | | | G1: 1.76 (1.69) (P = NS)
| | | G2: 12 (27%) | | | | | | G2: 2.08 (1.70) (P = NS)
| | | (P = NS) | | | | | | G2: 2.08 (1.70) (P = NS)
| | | Previous tx, N (%): | | | | | | Diff between groups (P = NS)
| | | G1: 36 (90%) | | | | | | Diff between groups in change over time (P = NS)
| | | G2: 39 (89%) | | | | | EDE- Wt Concerns, mean (SD): | EDE-Wt Concerns, mean (SD)
| | | (P = NS) | | | | | G1: 1.96 (1.52) | 6mos:
| | | Intact families, N (%) | | | | | G2: 2.32 (1.51) | G1: 1.62 (1.48) (P = NS)
| | | G1: 31 (74%) | | | | | (P = NS) | G2: 2.01 (1.50) (P = NS)
| | | G2: 36 (82%) | | | | | | Diff between groups (P = NS)
| | | (P = NS) | | | | | | Diff between groups in change over time (P = NS)
| | | Purgers, N (%): | | | | | | 1 yr:
| | | G1: 9 (21%) | | | | | | G1: 1.39 (1.44) (P = NS)
| | | G2: 7 (16%) | | | | | | G2: 1.97 (1.60) (P = NS)
| | | (P = NS) | | | | | | Diff between groups (P = NS)
| | | Restrictors, N (%): | | | | | | Diff between groups in change over time (P = NS)
| | | G1: 33 (79%) | | | | | YBC-ED-Total score, mean (SD): | YBC-ED-Total Score, mean (SD)
| | | G2: 37 (84%) | | | | | G1: 12.2 (8.4) | 6mos:
| | | (P = NS) | | | | | G2: 13.4 (7.9) | G1: 8.8 (6.6) (P = NS)
| | | | | | | | (P = NS) | G2: 10.9 (9.7) (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 1 yr:
| | | | | | | | | G1: 6.4 (6.4) (P = NS)
| | | | | | | | | G2: 9.2 (9.6) (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | A secondary analysis of moderators of outcome found:
| | | | | | | | | - For BMI, YBC-ED-total score moderated outcome in favor of longer tx (G1) for those with the most severe symptoms (P = 0.008).; - For global EDE, those with non-intact families did better in longer tx (P = 0.004).
| | | | | | | | | Sx Remission:
| | | | | | | | | - Using DSM IV BMI criterion (BMI < 17.5) only, 96% of the sample remitted at the end of tx; - Using criterion of BMI = 20 and a global EDE score within 2 SDs of normal, 67% would be considered remitted.
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | G1: Family seen conjointly, parents placed in control of eating, cognitive restructuring, behavioral interventions to change family interactions. Met wkly for mean of 72 m. | Univariate and Multivariate repeated-measures ANOVAs. Chi squares. | Score: | EAT, Teen, mean (SD): | EAT, Teen, mean (SD): post | BDI, mean (SD): | BDI, mean (SD): Post | BMI, mean (SD): | BMI, mean (SD): Post
Robin et al., 1999 | To compare the effectiveness of behavioral family systems therapy (BFST) with ego-oriented individual therapy (EOIT) in adolescents with AN. | G1: BFST (N = 19) | G1: 14.9 (P = NR) | Female; age 11–20; DSM III-R criteria for AN, residing at home with 1 or both parents. | G2: Adolescent seen individually, emphasis on building ego strength and uncovering dynamics blocking eating, parents seen collaterally. Adolescents met wkly for 45 m. Parents met bimonthly for mean of 54 m. | | Poor | G1: 32.6 (15.6) | G1: 11.2 (13.6) | G1: 19.4 (12.3) | G1: 8.5 (8.4) | G1: 15.2 (1.8) | G1: 19.9 (1.9)
Setting: | | G2: EOIT (N = 18) | G2: 13.4 (P = NR) | Exclusion: | G1 + G2: medical and dietary regimen. | | Intent to treat: | G2: 20.6 (15.6) | G2: 7.9 (9.6) | G2: 11.3 (10.5) | G2: 5.4 (9.0) | G2: 16.6 (2.1) | G2: 18.9 (1.9)
Outpt tx, MI, USA | | Enrollment: | (P < 0.05) | NR | Therapy length, mean mo (range): 15.9 (12–18). Wkly for the first half, bimoly thereafter. Post-assessment at termination | | No | | Change over time (P < 0.001) | | Change over time (P < 0.001) | | Change over time (P < 0.001)
Enrollment period: | | - 120 telephone screened; - 60 intake interviews; - 56 met criteria; - 41 enrolled; - 37 completed (G1: 19 G2: 18) | Sex: | | FU at 12 mos. | | Blinding: | | Diff between groups (P = NR) | | Diff between groups (P = NR) | | Diff between groups (P = NR)
1988-19947 | | 1 yr FU: | Female: 100% | | Diet: Balanced based on diabetic exchange, starting with 1200 cal/day and adjusted upward to permit 1 lb st gain/wk. | | NA | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P < 0.001)
| | N = 30 | Race/ethnicity, N: | | Hospitalizations, N: If < 75% of ideal wt and/or had cardiac problems, received refeeding program and assigned therapy. Discharged when exceeded 80% of target wt, no other medical distress, and gaining wt on regular basis. | | Adverse events: | | EAT, Teen, mean (SD): FU | | FU | | G1 > than G2
| | | White: 35 | | G1: 11 | | NR | | G1: 8.1 (10.0) | | G1: 10.5 (11.0) | | BMI, mean (SD): FU
| | | Middle Eastern: 2 | | G2: 5 | | Funding: | | G2: 4.7 (6.1) | | G2: 2.7 (4.7) | | G1: 20.7 (2.7)
| | | Hollingshead 4-factor index: SES, mean (SD): | | Psychoactive meds prescribed, N: | | NIMH | | Change over time (P < 0.001) | | Change over time (P < 0.001) | | G2: 19.8 (3.1)
| | | G1: 45.7 (13.6) | | G1: 2 | | | | Diff between groups (P = NR) | | Diff between groups (P = NR) | | Change over time (P < 0.001)
| | | G2: 47.9 (12.0) | | G2: 2 | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS) | | Diff between groups (P = NR)
| | | (P = NS) | | Due to OCD, MDD after wt gain | | | | | | | | Diff between groups in change over time (P < 0.02)
| | | Developed AN within previous 12 mos: | | | | | | | | | | Attained target wt, %: Post:
| | | 100% | | | | | | | | | | G1: 66.7
| | | Wt, lbs, mean: | | | | | | | | | | G2: 68.8
| | | G1: 86.5 | | | | | | | | | | Change over time (P = NR)
| | | G2: 86.8 | | | | | | | | | | Diff between groups (P = NS)
| | | (P = NS) | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | Height, inches, mean: | | | | | | | | | | Attained target wt, %: FU:
| | | G1: 63 | | | | | | | | | | G1: 80.0
| | | G2: 61 | | | | | | | | | | G2: 68.8
| | | (P = NS) | | | | | | | | | | Change over time (P = NR)
| | | Comorbidity assessed via DSM III Diagnostic Interview for Children and Adolescents: | | | | | | | | | | Diff between groups (P = NS)
| | | Mood disorder: 54% | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | Anxiety: 13% | | | | | | | | | | Attained 25 percentile BMI for age, %: Post:
| | | | | | | | | | | | | G1: 84.2
| | | | | | | | | | | | | G2: 82.4
| | | | | | | | | | | | | Change over time (P = NR)
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | | | Attained 25 percentile BMI for age, %: FU:
| | | | | | | | | | | | | G1: 86.7
| | | | | | | | | | | | | G2: 93.3
| | | | | | | | | | | | | Change over time (P = NR)
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | | | Attained 50 ^ th ^ percentile BMI for age, %: Post:
| | | | | | | | | | | | | G1: 52.6
| | | | | | | | | | | | | G2: 41.2
| | | | | | | | | | | | | Change over time (P = NR)
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | | | Attained 50 ^ th ^ percentile BMI for age, %: FU:
| | | | | | | | | | | | | G1: 66.7
| | | | | | | | | | | | | G2: 46.7
| | | | | | | | | | | | | Change over time (P = NR)
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | | | Resumed/Began menstruation, %, post:
| | | | | | | | | | | | | G1: 94
| | | | | | | | | | | | | G2: 64.4
| | | | | | | | | | | | | Change over time (P = NR)
| | | | | | | | | | | | | Diff between groups (P < 0.03)
| | | | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | | | Resumed/Began menstruation, %, FU:
| | | | | | | | | | | | | G1: 92.9
| | | | | | | | | | | | | G2: 80
| | | | | | | | | | | | | Change over time (P = NR)
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | 6 hr pre-assessment | 2x2 group (BFST vs EOIT) x time (Pre vs post) repeated measures ANOVA with Bonferroni correction for multiple comparison | Score:
Robin et al., 1994 | Compare the effectiveness of BFST to EOIT on wt gain, eating attitudes, family measures, ego functioning, depression, internalizing behavior and other psychometric measures in adolescents with AN, restricting sub-type. | G1: BFST (N = 12) | G1: 14.7 (2.7) | Dx of AN (restricting type) by DSM III-R criteria; onset within last 12 mos; lives at home with one or both parents; adolescent aged 12–19 | Randomized to BFST (G1) or EOIT (G2) | | Fair
Companion article: | | G2: EOIT (N = 12) | G2: 13.9 (2.1) | Exclusion: | Therapists (5) dedicated to 1 tx modality- standardized | | Intent to treat:
Robin, Siegel and Moye, 1995 | | Analysis in article presented on 22 completers only | (P = NS) | NR | 12–18 mos of tx determined by case with amount of therapy time equalized across modes | | No
Setting: | | Enrollment: | Sex: | | 6–9 mos of tx wkly, then 6–9 mos of tx bimoly | | Blinding:
One site: outpatient and inpatient hospital setting, USA | | - Referred by pediatricians, school personnel, psychologists, and social workers.; - Phone screen with parent; - Randomization to G1 or G2; - Comprehensive intake interview and pediatric medical exam; - Enrolled (N = 24) after confirmation of dx; - Completed (N = 22) | Female: 100% | | diet to gain 1 lb wt /wk | | No
Enrollment period: | | Drop-outs: | Race/ethnicity: | | Inpatient re-feeding if < 75% IBW until 80% or more of target wt., no other sig problems and gaining wt. Participants also hospitalized for sig cardiac or neurologic problems | | Adverse events:
NR | | G1 = 1 | Caucasian: 100% | | G2: collateral sessions for parents | | Patients hospitalized for an avg of 26.4 days:
| | G2 = 1 | SES (Hollingshead), mean (SD): | | 6-hr post-assessment (includes physical) | | BFST: 5
| | | G1: 44.5 (15.4) | | FU (Planned) at 12, 30 and 48 mo post-tx | | EOIT: 3
| | | G2: 44.5 (15.4) | | | | Funding:
| | | (P = NS) | | | | NIMH
| | | Target Wt (lbs), mean (SD):
| | | G1: 116.7 (10.7)
| | | G2: 108.3 (20.5)
| | | (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | 6 hr pre-assessment | t-tests to determine initial diffs between groups at pre-assessment | Score: | EAT, mean (SD): Adolescent | EAT, mean (SD): Adolescent | BSQ, mean (SD): | BSQ, mean (SD): | Wt (lbs), mean (SD):
Robin, Siegel and Moye, 1995 | In an adolescent AN, restricting sub-type population, compare the impact of behavioral family systems therapy (BFST) vs. ego-oriented individual therapy (EOIT) on family interactions including communication, problem-solving, warmo/hostility using self-report and observational measures of conflict and negative communication concerning eating and non-eating issues at end of tx and 1-yr FU. | G1: BFST (N = 12) | G1: 14.7 (2.7) | Dx of AN (restricting type) by DSM III-R criteria; onset within last 12 mos; lives at home with one or both parents; adolescent aged 12–19 | Randomized to BFST (G1) or EOIT (G2) | 2x2 group (BFST vs EOIT) x time (Pre vs post) repeated measures ANOVA | Fair | G1: 33.3 (16.7) | G1: 7.2 (7.8) (P = NR) | G1: 106.0 (40.3) | G1: 53.1 (42.8) (P = NR) | G1: 85.4 (12.7)
Companion article: | | G2: EOIT (N = 12) | G2: 13.9 (2.1) | Exclusion: | Therapists (5) dedicated to 1 tx modality- standardized | orthogonal, repeated measures linear contrasts with tx condition as the grouping factor: Contrast I = pre-assessment vs. FU; Contrast II = post-assessment vs. FU | Intent to treat: | G2: 18.0 (14.7) | G2: 4.1 (7.9) (P = NR) | G2: 69.3 (47.1) | G2: 43.4 (38.9) (P = NR) | G2: 91.0 (23.1)
Robin et al., 1994 | | G3: BFST at FU (N = 11) | (P = NS) | NR | 12–18 mos of tx determined by case with amount of therapy time equalized across modes | Bonferroni correction for multiple comparisons. | No | (P = NR) | Diff over time (P < 0.001) | (P = NR) | Diff over time (P < 0.001) | (P = NS)
Setting: | | G4: EOIT at FU (N = 9) | Sex: | | 6–9 mos of tx wkly, then 6–9 mos of tx bimoly | | Blinding: | | Diff between groups (P = NR) | | (P = NR)
One site: outpatient and inpatient hospital setting, USA | | Enrollment: | Female: 100% | | diet to gain 1 lb wt /wk | | No | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
Enrollment period: | | - Referred by pediatricians, school personnel, psychologists, and social workers.; - Phone screen with parent; - Randomization to G1 or G2; - Comprehensive intake interview and pediatric medical exam; - Enrolled (N = 24) after confirmation of dx; - Completed (N = 22) | Race/ethnicity: | | Inpatient re-feeding if < 75% IBW until 80% or more of target wt., no other sig problems and gaining wt. Participants also hospitalized for sig cardiac or neurologic problems | | Adverse events: | EAT, mean (SD): Mother | EAT, mean (SD): Mother | EDI, mean (SD): | EDI, mean (SD): | BMI (kg/m ^ 2 ^ ), mean (SD) | BMI (kg/m ^ 2 ^ ), mean (SD):
NR | | | White: 100% | | G2: collateral sessions for parents | | Patients hospitalized for an avg of 26.4 days: | G1: 42.8 (10.9) | G1: 6.0 (6.8) (P = NR) | Body dissatisfaction | Body dissatisfaction | G1: 15.0 (1.4) | G1: 20.1 (1.1) (P = NR)
| | | | | 6-hr post-assessment (includes physical) | | BFST: 5 | G2: 36.3 (15.8) | G2: 12.6 (11.8) (P = NR) | G1: 10.4 (8.3) | G1: 6.5 (9.2) (P = NR) | G2: 16.3 (2.8) | G2: 19.0 (1.4) (P = NR)
| | | | | FU (Planned) at 12, 30 and 48 mo post-tx | | EOIT: 3 | (P = NR) | Diff over time (P < 0.001) | G2: 9.8 (7.8) | G2: 8.8 (9.9) (P = NR) | (P = NS) | Diff over time (P < 0.001)
| | | | | 6-hr post-assessment (includes physical) | | Funding: | | Diff between groups (P = NR) | (P = NR) | Diff over time (P = NS) | %Underwt, mean (SD): | (P = NR)
| | | | | 12 mo FU assessment | | NIMH | | Diff between groups in change over time (P = NS) | | Diff between groups (P = NR) | G1: 26.9 (8.3) | Diff between groups in change over time (P < 0.01)
| | | | | | | | | | | Diff between groups in change over time (P = NS) | G2: 16.4 (10.6) | G1 better than G2
| | | | | | | | | | | | (P < 0.05) | ≥ 50 ^ th ^ percentile BMI for age
| | | | | | | | | | | | | G1: 73%
| | | | | | | | | | | | | G2: 45%
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | | | | | Menstruating at post-assessment
| | | | | | | | | | | | | G1: 89%
| | | | | | | | | | | | | G2: 60%
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EAT, mean (SD): Father | EAT, mean (SD): Father | BDI, mean (SD): | BDI, mean (SD):
| | | | | | | | G1: 41.3 (12.6) | G1: 12.6 (16.9) (P = NR) | G1: 21.4 (11.3) | G1: 6.7 (8.0) (P = NR)
| | | | | | | | G2: 36.6 (15.9) | G2: 20.4 (14.4) (P = NR) | G2: 12.1 (12.8) | G2: 6.2 (10.9) (P = NR)
| | | | | | | | (P = NR) | Diff over time (P < 0.001) | (P = NR) | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | | Eating Conflict (T scores) from PARQ, mean (SD): Adolescent | Eating Conflict (T scores) from PARQ, mean (SD):Adolescent | | | | FU:
| | | | | | | | G1: 76.4 (21.7) | G1: 55.0 (16.6) (P = NR) | | | | BMI (kg/m ^ 2 ^ ):
| | | | | | | | G2: 74.0 (16.1) | G2: 59.5 (21.1) (P = NR) | | | | G3: 21.5 (2.7) (P = NR)
| | | | | | | | (P = NS) | Diff over time (P < 0.01) | | | | G4: 19.3 (2.2) (P = NR)
| | | | | | | | | Diff between groups (P = NR) | | | | Diff over time
| | | | | | | | | Diff between groups in change over time (P = NS) | | | | - vs. pre-tx (P < 0.001); - vs. post-tx (P = NS)
| | | | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | | | Diff between groups in change over time (Pre-tx: P < 0.004)
| | | | | | | | | | | | | G3 better than G4
| | | | | | | | Eating Conflict (T scores) from PARQ, mean (SD): Mother | Eating Conflict (T scores) from PARQ, mean (SD): Mother | | | | Achieved target wt (post-assessment)
| | | | | | | | G1: 88.5 (17.6) | G1: 52.0 (13.9) (P = NR) | | | | G1: 64%
| | | | | | | | G2: 96.3 (18.1) | G2: 58.8 (17.1) (P = NR) | | | | G2: 64%
| | | | | | | | (P = NS) | Diff over time (P < 0.001)(P = NR) | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS) | | | | Achieved target wt (FU)
| | | | | | | | | | | | | G3: 82%
| | | | | | | | | | | | | G4: 50%
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | Eating Conflict (T scores) from PARQ, mean (SD): Father | Eating Conflict (T scores) from PARQ, mean (SD): Father | | | | Menstruating (at post-assessment)
| | | | | | | | G1: 76.7 (19.1) | G1: 46.8 (11.5) (P = NR) | | | | G1: 89%
| | | | | | | | G2: 86.1 (20.1) | G2: 52.3 (22.0) (P = NR) | | | | G2: 60%
| | | | | | | | (P = NS) | Diff over time (P < 0.001) | | | | G3: 90%
| | | | | | | | | Diff between groups (P = NR) | | | | G4: 73%
| | | | | | | | | Diff between groups in change over time (P = NS) | | | | Diff between groups (P = NS)
| | | | | | | | Interaction Behavior Code (IBC) of Conflict During Discussion of Adolescent's Eating/Wt Problem: | IBC Of Conflict OverEating: | | | | Menstruating (at FU)
| | | | | | | | Negative communication, mean (SD): Adolescent | Negative communication, mean (SD): Adolescent | | | | G3: 100%
| | | | | | | | G1: 6.1 (3.5) | G1: 2.2 (1.9) (P = NR) | | | | G4: 100%
| | | | | | | | G2: 7.5 (4.5) | G2: 3.9 (2.4) (P = NR) | | | | Diff between groups (P = NS)
| | | | | | | | (P = NS) | Diff over time (P < 0.003)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Negative communication, mean (SD): Mother | Negative communication, mean (SD): Mother
| | | | | | | | G1: 5.5 (3.3) | G1: 1.4 (1.4) (P < 0.002)
| | | | | | | | G2: 4.1 (2.5) | G2: 3.4 (4.3) (P = NS)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.04)
| | | | | | | | | G1 better than G2
| | | | | | | | Negative communication, mean (SD): Father | Negative communication, mean (SD): Father
| | | | | | | | G1: 6.1 (4.1) | G1: 3.4 (3.5)
| | | | | | | | G2: 6.4 (3.7) | G2: 3.5 (3.0)
| | | | | | | | (P = NS) | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Positive communication, mean (SD): Adolescent | Positive communication, mean (SD): Adolescent
| | | | | | | | G1: 1.3 (1.0) | G1: 2.3 (1.2)
| | | | | | | | G2: 0.9 (0.6) | G2: 1.7 (1.6)
| | | | | | | | (P = NS) | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Positive communication, mean (SD): Mother | Positive communication, mean (SD): Mother
| | | | | | | | G1: 1.6 (1.4) | G1: 3.1 (1.6) (P < 0.005)
| | | | | | | | G2: 2.5 (1.3) | G2: 2.2 (1.3) (P = NS)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | G1 better than G2
| | | | | | | | Positive communication, mean (SD): Father | Positive communication, mean (SD): Father
| | | | | | | | G1: 1.2 (1.2) | G1: 3.5 (1.4)
| | | | | | | | G2: 1.3 (0.8) | G2: 2.6 (0.9)
| | | | | | | | (P = NS) | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 1 yr FU:
| | | | | | | | | Eating Conflict (T scores) from PARQ, mean (SD):
| | | | | | | | | Adolescent:
| | | | | | | | | G3: 56.0 (21.8) (P = NR)
| | | | | | | | | G4: 55.6 (14.2) (P = NR)
| | | | | | | | | Change over time
| | | | | | | | | - vs. pre-tx (P < 0.006); - vs. post-tx (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Mother:
| | | | | | | | | G3: 54.0 (16.3) (P = NR)
| | | | | | | | | G4: 65.9 (13.0) (P = NR)
| | | | | | | | | Change over time
| | | | | | | | | - vs. pre-tx (P < 0.001); - vs. post-tx (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Father:
| | | | | | | | | G3: 53.3 (16.8) (P = NR)
| | | | | | | | | G4: 59.9 (18.0) (P = NR)
| | | | | | | | | Change over time
| | | | | | | | | - vs. pre-tx (P < 0.001); - vs. post-tx (P < 0.02)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age at onset, mean (SD): | Inclusion: | Upon reaching near-healthy body wt and being discharged from inpatient tx, patients were randomly assigned to conditions which were delivered on an outpt basis for one yr. Tx lasted 1 hour at least fortnightly for first 3 mos, then once every three wks for a total of 1 yr from date of discharge. | t-tests, Fisher's exact probability test. Mulitivariate analyses and ANCOVAs | Score: | M-R Scales, Nutritional Status, mean (SD): Subgroup 1: | M-R Scales, Nutritional Status at one year, mean (SD): Subgroup 1: | M-R Scales, Mental State, mean (SD): | M-R Scales, Mental State mean (SD): | ABW at discharge, %, mean (SD): | ABW at one year, %, mean (SD):
Russell et al., 1987 | To compare family therapy with individual supportive therapy in AN and BN. | G1: Family Therapy (N = 41) | 17.9 (6.4) | AN: DSM III criteria; self-induced wt loss through avoidance of fattening foods, excessive exercise, and self-induced vomiting or purging (not following binge eating); idea that fatness is a dreadful state; specific endocrine disorder (amenorrhea or in males sexual interest/potency lost). | G1: Family therapy: Included all members of the household. Tasks: family cooperation, organization (communication, rules), interventions (management, cooperation, support, consistency) | | Fair | G1: 0.7 (1.0) | G1: 9.6 (1.7) | Subgroup 1: | Subgroup 1: | Subgroup 1: | Subgroup 1:
Companion article: | | G2: Individual Therapy (N = 39) | (P = NS) | BN: DSM III-R preoccupation with food and episodes of gross overeating; counteract fattening effects of food by vomiting, purging, or starvation; psychopathology similar to AN; hx of previous overt or minor episode of AN. | G2: Nonspecific form of individual therapy: supportive, educational, problem-centered | | Intent to treat: | G2: 1.3 (1.4) | G2: 5.2 (3.3) | G1: 10.0 (2.8) | G1: 12.0 (0.0) | G1: 89.4 (6.9) | G1: 92.8 (8.4)
Eisler et al., 1997 | | Enrollment: | Age at entry to trial, mean (SD): | Exclusion: | Antidepressant drug use allowed for both groups. | | Yes | (P = NS) | Diff between groups (P = NR) | G2: 8.7 (3.0) | G2: 10.2 (2.1) | G2: 88.4 (8.1) | G2: 80.1 (15.1)
Setting: | | Following inpatient stay, patients randomly assigned after determined to be in 1 of 4 subgroups: | 21.8 (7.1) | NR | Number of sessions, mean (SD): | | Blinding: | | Diff between groups in change over time (P < 0.001) | Diff between groups | Diff between groups (P = NR) | Diff between groups | Diff between groups
Outpt tx: Maudsley Hospital, London, UK | | 1) AN, age of onset ≤ 18 yrs and duration < 3 yrs (N = 21) | (P = NS) | Inclusion: | G1: 10.5 (8.9) | | N/A | | G1 better than G2 | (P = NS) | Diff between groups over time (P = NS) | (P = NR) | (P = NR)
Enrollment period: | | 2) AN, onset ≤ 18 yrs and duration > 3 yrs (N = 15) | Duration of illness, y, mean (SD): | AN: DSM III criteria; self-induced wt loss through avoidance of fattening foods, excessive exercise, and self-induced vomiting or purging (not following binge eating); idea that fatness is a dreadful state; specific endocrine disorder (amenorrhea or in males sexual interest/potency lost). | G2: 15.9 (8.5) | | Adverse events: | | | Subgroup 4: | Subgroup 4: | Subgroup 2: | Diff between groups in change over time (P < 0.01)
NR | | 3) AN, onset ≥ 19 yrs (N = 21) | 3.8 (3.1) | BN: DSM III-R preoccupation with food and episodes of gross overeating; counteract fattening effects of food by vomiting, purging, or starvation; psychopathology similar to AN; hx of previous overt or minor episode of AN. | (P < 0.01) | | NR | | | G1: 9.8 (2.9) | G1: 9.3 (2.8) | G1: 91.3 (4.9) | G1 better than G2
| | 4) BN (N = 23) | (P = NS) | Exclusion: | | | Funding: | | | G2: 7.6 (3.0) | G2: 10.8 (2.7) | G2: 92.1 (6.4) | Subgroup 2:
| | - Randomized: N = 80; - Analyzed: N = 73 (did not begin tx: G1: 5, G2: 2); - Dropout/Tx Refusers, N: 28 | Wt on admission, % ABW, mean (SD): | NR | | | Medical Research Council, UK | | | Diff between groups | Diff between groups (P = NR) | Diff between groups | G1: 81.7 (9.0)
| | Subgroup 1: | 69.6 (13.0) | | | | | | | (P = NS) | Diff between groups over time (P < 0.001) | (P = NR) | G2: 80.3 (15.3)
| | G1: 1 | (P = NS) | | | | | | | | G2 > G1 | Subgroup 3: | Diff between groups
| | G2: 7 | Wt on discharge, % ABW, mean (SD): | | | | | | | | Subgroups 2–3: | G1: 84.9 (8.8) | (P = NR)
| | (P < 0.02) | 89.5 (7.1) | | | | | | | | G1: NR | G2: 86.6 (6.7) | Diff between groups in change over time (P = NS)
| | Subgroup 2: | (P = NS) | | | | | | | | G2: NR | Diff between groups | Subgroup 3:
| | G1: 3 | Duration of index hospital stay, wk, mean: | | | | | | | | Diff between groups in change over time (P = NS) | (P = NR) | G1: 71.1 (8.3)
| | G2: 4 | 10.4 | | | | | | | | | Subgroup 4: | G2: 79.9 (13.1)
| | (P = NR) | G1: 8.8 | | | | | | | | | G1: 91.2 (8.3) | Diff between groups
| | Subgroup 3: | G2: 12.1* | | | | | | | | | G2: 87.8 (4.9) | (P = NR)
| | G1: 4 | (P = NR) | | | | | | | | | Diff between groups | Diff between groups in change over time (P < 0.03)
| | G2: 0 | Subgroup 1: | | | | | | | | | (P = NR) | G2 better than G1.
| | (P < 0.05) | G1: 8.6 | | | | | | | | | | Subgroup 4:
| | Subgroup 4: | G2: 11.8 | | | | | | | | | | G1: 989.0 (13.1)
| | G1: 7 | (P < 0.05) | | | | | | | | | | G2: 86.2 (11.5)
| | G2: 2 | Subgroup 2: | | | | | | | | | | Diff between groups
| | (P = NR) | G1: 8.2 | | | | | | | | | | (P = NR)
| | Diff between subgroups (P = NS) | G2: 13.0 | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | (P < 0.02) | | | | | | Subgroups 2–4: | M-R Scales, Psychosexual adjustment, mean (SD): | M-R Scales, Psychosexual adjustment at one year, mean (SD): | | Wt maintenance >85% ABW from discharge to post tx at one year, N:
| | | Previous admissions, N, mean: 1.5 | | | | | | Data not shown | Subgroup 1: | Subgroup 1: | | Subgroup 1:
| | | (P = NS) | | | | | | Diff between groups in change over time (P = NS) | G1: 6.3 (3.2) | G1: 9.4 (3.0) | | G1: 5/10
| | | Sex, N | | | | | | | G2: 5.6 (2.4) | G2: 6.3 (1.8) | | G2: 1/11
| | | Male: 7 | | | | | | | Diff between groups | Diff between groups | | Diff between groups (P < 0.05)
| | | Female: 73 | | | | | | | (P = NS) | (P = NR) | | Subgroup 2:
| | | (P = NS) | | | | | | | | Diff between groups over time (P < 0.05) | | G1: 4/10
| | | Race/ethnicity: | | | | | | | | G1 better than G2. | | G2: 3/9
| | | NR | | | | | | | | Subgroups 2–4: | | Diff between groups (P = NS)
| | | Marital status, N: | | | | | | | | G1: NR | | Subgroup 3:
| | | Single: 69 | | | | | | | | G2: NR | | G1: 1/7
| | | Married: 8 | | | | | | | | Diff between groups in change over time (P = NS) | | G2: 2/7
| | | Separated/divorced: 3 | | | | | | | | | | Diff between groups (P = NS)
| | | (P = NS) | | | | | | | | | | Subgroup 4:
| | | Social Class, N: | | | | | | | | | | G1: 6/9
| | | I: 23 | | | | | | | | | | G2: 5/10
| | | II: 28 | | | | | | | | | | Diff between groups (P = NS)
| | | III: 21 | | | | | | Readmission rate, N (%): 22 | | | M-R Scales, Menstrual function, mean (SD): Subgroup 1: | M-R Scales, Menstrual function at one year, mean (SD): Subgroup 1:
| | | IV: 6 | | | | | | G1: 9 (25) | | | G1: 0.0 (0) | G1: 5.5 (6.0)
| | | V: 2 | | | | | | G2: 13 (35) | | | G2: 0.0 (0) | G2: 0.8 (2.5)
| | | Diff between groups (P = NS) | | | | | | Diff between groups (P = NS) | | | Diff between groups | Diff between groups (P = NR)
| | | Living with: | | | | | | | | | (P = NS) | Diff between groups over time (P < 0.02)
| | | Parents: 60 | | | | | | | | | | G1 better than G2.
| | | Spouse/cohabitant: 12 | | | | | | | | | | Subgroups 2–4:
| | | Alone: 8 | | | | | | | | | | G1: NR
| | | Diff between groups (P = NS) | | | | | | | | | | G2: NR
| | | Distance from hospital, km, N: | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | < 24: 28 | | | | | | | M-R Scales, Socioeconomic status, mean (SD): | M-R Scales, Socioeconomic status at one year, mean (SD): | | M-R scales outcome at one year, N:
| | | 25 – 80: 28 | | | | | | | Subgroup 1: | Subgroup 1: | | Subgroup 1:
| | | 81 – 240: 16 | | | | | | | G1: 9.2 (2.1) | G1: 10.8 (1.9) | | G1: Good: 6
| | | > 240: 8 | | | | | | | G2: 8.1 (3.5) | G2: 7.4 (3.4) | | Intermediate: 3
| | | Diff between groups (P = NS) | | | | | | | (P = NS) | Diff between groups (P = NR) | | Poor: 1
| | | | | | | | | | | Diff between groups over time (P < 0.03) | | G2: Good: 1
| | | | | | | | | | | G1 better than G2 | | Intermediate: 1
| | | | | | | | | | | Subgroups 2–4: | | Poor: 9
| | | | | | | | | | | G1: NR | | Diff between good and combined intermediate and poor (P = 0.02)
| | | | | | | | | | | G2: NR | | Diff between poor and combined intermediate and good (P < 0.002)
| | | | | | | | | | | Diff between groups in change over time (P = NS) | | Subgroup 2:
| | | | | | | | | | | | | G1: Good: 2
| | | | | | | | | | | | | Intermediate 2: Poor: 6
| | | | | | | | | | | | | G2: Good: 2
| | | | | | | | | | | | | Intermediate 1: Poor: 6
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | | | Subgroup 3:
| | | | | | | | | | | | | G1: Good: 0
| | | | | | | | | | | | | Intermediate: 1
| | | | | | | | | | | | | Poor: 6
| | | | | | | | | | | | | G2: Good: 2
| | | | | | | | | | | | | Intermediate: 1
| | | | | | | | | | | | | Poor: 4
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | | | Subgroup 4:
| | | | | | | | | | | | | G1: Good: 0
| | | | | | | | | | | | | Intermediate: 1
| | | | | | | | | | | | | Poor: 8
| | | | | | | | | | | | | G2: Good: 1
| | | | | | | | | | | | | Intermediate: 2
| | | | | | | | | | | | | Poor: 7
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | M-R Scales, Avg outcome. mean (SD): | M-R Scales, Avg Outcome at one year, mean (SD):
| | | | | | | | | | Subgroup 1: | Subgroup 1:
| | | | | | | | | | G1: 5.5 (1.3) | G1: 9.7 (2.0)
| | | | | | | | | | G2: 4.8 (1.4) | G2: 5.7 (2.0)
| | | | | | | | | | Diff between groups (P = NS) | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups over time (P < 0.01). G1 better than G2.
| | | | | | | | | | | Subgroups 2–4:
| | | | | | | | | | | G1: NR
| | | | | | | | | | | G2: NR
| | | | | | | | | | | Diff between groups in change over time (P = NS)

Evidence Table 5. Medication trials for bulimia nervosa

| | | | | | | | Eating Related Measures | | Psychological/Psychiatric Measures | | Biomarkers
Study Description | Objective | Design | Patient Characteristics | Inclusion/Exclusion Criteria | Treatment | Statistical Methods | Quality | Baseline | Outcomes | Baseline | Outcomes | Baseline | Outcomes
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | All participants received nutritional counseling for 8 wks from same dietitian, along with random allocation to fluoxetine or placebo. Fluoxetine group: 20 mg 3 times a day with initial placebo washout period for 7–10 days. After washout, participants began trial and seen wkly until active tx ceased. FU assessments were made 4 wks after meds was stopped and 8 wks after that. The participants were all seen by the same research nurse, general practitioner and dietitian. | Mann-Whitney U tests, t-tests, median tests and chi-squared tests used to test Diffs. | Score: | Total number of bulimic episodes, mean (SD): | Wk 4: | | | Wt, kgs, mean (SD): | Wk 4:
Beumont et al., 1997 | Efficacy of nutritional counseling in treating BN and whether improvement is maintained. Examine additional benefit of fluoxetine. | G1: Fluoxetine (N = 34) | G1: 24.2 (4.5) | Women; at least 18 yrs old; fulfilled DSM III-R criteria for BN; within normal, healthy wt range with BMI between 20 and 25. | | | Fair | G1: 10.1 (10.1) | Total number of bulimic episodes, mean (SD): | | | G1: 60.5 (6.2) | Wt, kgs:
Setting: | | G2: Placebo (N = 33) | G2: 25.1 (5.8) | Exclusion: | | | Intent to treat: | G2: 6.1 (5.6) | G1: 1.9 (3.4) (P < 0.0001) | | | G2: 60.9 (6.9) | G1: NR (P = NR)
University-based outpatient clinics, Australia | | Enrollment: | Sex: | Use of appetite suppressant or monoamine oxidase inhibitor within 2 wks of starting study or other psychotropic meds within one wk; presence of medical illness, psychosis or suicidal ideation; hx of drug abuse, bipolar depression, mania or hypomania; pregnancy, lactation or being of child bearing age, not using medically accepted means of contraception; previous participation in any fluoxetine study or use of fluoxetine in last 5 wks; electrolyte levels outside normal range. | | | Yes | (P = NS) | G2: 1.5 (2.4) (P < 0.0001) | | | | G2: NR (P = NR)
Enrollment period: | | Participants recruited from two university-affiliated tx centers and from tertiary referrals from other psychiatric units. | Female: 100% | | | | Blinding: | | Diff between groups (P = NS) | | | | Diff between groups (P = NR)
NR | | - Consecutive patients who met criteria were offered participation and asked for consent.; - Participants received defined nutritional counseling program each wk (for 8 wks) in a one-one setting and randomly allocated to fluoxetine or placebo.; - After initial interview, placebo washout period for 7–10 days.; - 49 participants completed tx; - Of these, 40 took part in the final FU assessment (G1: 17; G2: 23) | Race/ethnicity: | | | | Double | | Diff between groups in change over time (P = NR) | | | | Diff between groups in change over time (P < 0.03)
| | | NR | | | | Adverse events: | | Wk 8: | | | | G1 > wt loss than G2
| | | | | | | Insomnia, nausea, and shakiness sig more common in G1. Depression more common in G2. Tiredness and headaches present equally in both groups. | | Mean total number of bulimic episodes (SD): | | | | Wk 8:
| | | | | | | Funding: | | G1: 1.6 (3.21) (P < 0.0001) | | | | Wt, kgs:
| | | | | | | Eli Lilly of Australia | | G2: 1.2 (2.0) (P < 0.0001) | | | | G1: NR (P = NR)
| | | | | | | | | Diff between groups (P = NS) | | | | G2: NR (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR) | | | | Diff between groups (P = NR)
| | | | | | | | | 3 mo FU: | | | | Diff between groups in change over time (P < 0.03)
| | | | | | | | | Total number of bulimic episodes, mean (SD): | | | | G1 > wt loss than G2
| | | | | | | | | G1: 2.2 (3.8) (P < 0.003) | | | | 3 mo FU:
| | | | | | | | | G2: 1.0 (3.3) (P < 0.001) | | | | Wt increase, kgs, above baseline mean:
| | | | | | | | | Diff between groups (P = NS) | | | | G1: 2.4 (P < 0.01)
| | | | | | | | | Diff between groups in change over time (P = NR) | | | | G2: NR (P = NS)
| | | | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Vomiting episodes per wk, mean (SD): | Wk 4: | HDRS, mean (SD): | HDRS, mean (SD):
| | | | | | | | G1: 8.8 (7.4) | Vomiting episodes per wk, mean (SD): | G1: 11 (5) | G1: 5.3 (5.5) (P = NS)
| | | | | | | | G2: 7.3 (6.5) | G1: 3.2 (7.4) (P = 0.0001) | G2: 11.8 (4.4) | G2: 6.8 (6.4) (P = NS)
| | | | | | | | (P = NS) | G2: 2.8 (3.6) (P = 0.001) | (P = NS) | Diff between groups (P = NS)
| | | | | | | | | Diff between groups (P = NS) | | Diff between groups in change over time (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Wk 8:
| | | | | | | | | Vomiting episodes per wk, mean (SD):
| | | | | | | | | G1: 1.2 (3.0) (P = 0.0001)
| | | | | | | | | G2: 2.3 (3.3) (P = 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 3 mo FU:
| | | | | | | | | Vomiting episodes per wk, mean (SD):
| | | | | | | | | G1: 2.5 (4.6) (P = 0.009)
| | | | | | | | | G2: 2.3 (3.3) (P = 0.003)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | BSQ, mean (SD): | Wk 4:
| | | | | | | | G1: 142 (288) | BSQ, mean (SD):
| | | | | | | | G2: 137 (26) | G1: NR (P < 0.0001)
| | | | | | | | (P = NS) | G2: NR (P < 0.0001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Wk 8:
| | | | | | | | | BSQ:
| | | | | | | | | G1: NR (P < 0.001)
| | | | | | | | | G2: NR (P < 0.0001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Wk 8:
| | | | | | | | | Abstinence from binge eating:
| | | | | | | | | G1: 69.6%
| | | | | | | | | G2: 61.5%
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | 3 mo FU:
| | | | | | | | | Abstinence from binge eating:
| | | | | | | | | G1: 35.7%
| | | | | | | | | G2: 60.9%
| | | | | | | | EAT score, mean (SD): | Wk 4:
| | | | | | | | G1: 49 (17) | EAT score:
| | | | | | | | G2: 40 (15) | G1: NR (P < 0.005)
| | | | | | | | (P = 0.04) | G2: NR (P < 0.005)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Wk 8:
| | | | | | | | | EAT score:
| | | | | | | | | G1: NR (P < 0.005)
| | | | | | | | | G2: NR (P < 0.005)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 3 mo FU:
| | | | | | | | | EAT score:
| | | | | | | | | G1: NR
| | | | | | | | | G2: NR
| | | | | | | | EDE - Restraint, mean (SD): | Wk 8:
| | | | | | | | G1: 3.5 (1.5) | EDE - Restraint, mean (SD):
| | | | | | | | G2: 3.4 (1.4) | G1: 1.0 (1.3) (P < 0.05)
| | | | | | | | (P = NS) | G2: 2.0 (1.4) (P < 0.05)
| | | | | | | | | Diff between groups (P < 0.03)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 3 mo FU:
| | | | | | | | | EDE - Restraint, mean (SD):
| | | | | | | | | G1: 1.7 (1.7) (P < 0.05)
| | | | | | | | | G2: 1.7 (1.8) (P < 0.05)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE - Overeating, mean (SD): | Wk 8:
| | | | | | | | G1: 2.4 (0.8) | EDE - Overeating, mean (SD):
| | | | | | | | G2: 2.1 (1.0) | G1: 0.9 (1.0) (P < 0.05)
| | | | | | | | (P = NS) | G2: 1.2 (1.0) (P < 0.05)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 3 mo FU:
| | | | | | | | | EDE - Overeating, mean (SD):
| | | | | | | | | G1: 1.4 (1.3) (P < 0.05)
| | | | | | | | | G2: 1.0 (1.1) (P < 0.05)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE - Eating Concern, mean (SD): | Wk 8:
| | | | | | | | G1: 3.1 (1.4) | EDE - Eating Concern, mean (SD):
| | | | | | | | G2: 2.7 (1.6) | G1: 1.1 (1.2) (P < 0.05)
| | | | | | | | (P = NS) | G2: 1.4 (1.2) (P < 0.05)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 3 mo FU:
| | | | | | | | | EDE - Eating Concern, mean (SD):
| | | | | | | | | G1: 1.6 (1.7) (P < 0.05)
| | | | | | | | | G2: 1.4 (1.5) (P < 0.05)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE - Shape Concern, mean (SD): | Wk 8:
| | | | | | | | G1: 3.7 (1.3) | EDE - Shape Concern, mean (SD):
| | | | | | | | G2: 3.9 (1.2) | G1: 2.0 (1.3) (P < 0.05)
| | | | | | | | (P = NS) | G2: 2.9 (1.5) (P < 0.05)
| | | | | | | | | Diff between groups (P < 0.03)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 3 mo FU:
| | | | | | | | | EDE - Shape Concern, mean (SD):
| | | | | | | | | G1: 3.0 (1.5) (P < 0.05)
| | | | | | | | | G2: 2.6 (1.6) (P < 0.05)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE - Wt Concern, mean (SD): | Wk 8:
| | | | | | | | G1: 3.0 (1.5) | EDE - Wt Concern, mean (SD):
| | | | | | | | G2: 3.0 (1.5) | G1: 1.2 (0.8)
| | | | | | | | (P = NS) | G2: 2.4 (1.6)
| | | | | | | | | Diff between groups (P < 0.03)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 3 mo FU:
| | | | | | | | | EDE - Wt Concern, mean (SD):
| | | | | | | | | G1: 2.0 (1.7) (P = NS)
| | | | | | | | | G2: 2.2 (1.6) (P < 0.05)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SE) (range): | Inclusion: | Pre-screening with HAM-D, BITE, EDI, and TFEQ | Between-group diffs in outcomes assessed using an unspecified parametric test for numerical variables and a non-parametric test for categorical variables. | Score: | Pre-Placebo Run-in (N = 78): | Post-Treatment: | Pre-Placebo Run-In (N = 78): | | Pre-Placebo Run-in (N = 78): | Post-tx (N = 52):
Carruba et al., 2001 | To examine the efficacy and tolerability of the MAOI-A moclobemide versus placebo in the tx of BN. | G1: Moclobemide (N = 28) | G1: 25.65 (0.78) (19–36) | Age 18 to 40; DSM IV criteria for BN | Initial 1-wk single-blind run in phase to identify and exclude placebo responders (i.e., 50% reduction of binge eating). | Efficacy and safety frequency data evaluated using a non-parametric test, and psychometric data compared using ANOVA. | Fair | Binge Episodes, wkly, mean (SE): | Binge Episodes, wkly, mean (SE): | HAM-D, mean (SE) (range): | HAM-D, mean (SE): | Ht, cm (SE) (range): | Wt, kg, mean (SE):
Setting: | | G2: Placebo (N = 24) | G2: 25.15 (0.9) (18–40) | Exclusion: | Randomization: | | Intent to treat: | G1: 6.24 (1.04) | G1: 4.84 (0.79) (P = NR) | G1: 8.14 (0.90) (2–22) | G1: 6.22 (0.99) (P = NR) | G1: 165.28 (1.04) (150–179) | G1: NR (P = NR)
3 Eating Disorder Units, Italy | | Enrollment: | (P = NS) | Hypersensitivity to MAOIs; neurological disorders; hx of schizophrenia, bipolar (I or II), suicide attempts, recent substance abuse; current dx of major depressive episode, high suicidal risk, unstable or uncontrolled medical diseases, clinically sig ECG; BMI < 17 or > 27; received psychotropic meds in past 4 wks | G1: 400mg for 1 wk, 600mg wk 2–6 | | No | G2: 6.46 (0.96) | G2: 3.61 (0.97) (P = NR) | G2: 9.43 (1.28) (1–22) | G2: 6.26 (1.26) (P = NR) | G2: 163.56 (0.87) (153–173) | G2: NR (P = NR)
Enrollment period: | | - 78 (of 103 patients seen in 3 ED Units) recruited; - 77 met criteria after placebo run-in phase; - 52 completed trial | Sex: | | G2: NR | | Blinding: | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups
6 consecutive mos | | Drop outs: | Female: 100% | | Daily diaries to record binge eating, purging, or non-purging compensatory behaviors. | | Double | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS) | | Diff between groups (P = NR)
| | G1: 10 (4 adverse events) | Race/ethnicity: | | 6 wkly sessions to collect diaries, record blood pressure, evaluate change in sx, effects, compliance, and to complete questionnaires. | | Adverse events, N (%): | Vomiting Episodes, wkly, mean (SE): | Vomiting Episodes, wkly, mean (SE): | | | Wt, kg, mean (SE) (range): | BMI, kg/m^2^; (SE):
| | G2: 15 (5 adverse events) | NR | | | | G1: respiratory infectious disease, 3 (7.9%); vertigo, 2 (5.3%); derealization crisis, 1 (2.6%); headache, 1 (2.6%); skin rash, 1 (2.6%); sleep disturbances, 1 (2.6%). | G1: 4.80 (1.03) | G1: 4.44 (1.06) (P = NR) | | | G1: 55.76 (1.36) (41–75) | G1: NR (P = NR)
| | | | | | | G2: headache, 2 (5.2%); sleep disturbances, 3 (7.8%); abdominal pain, 1 (2.6%); attention difficulty, 1 (2.6%); chest pain, 1 (2.6%); constipation, 1 (2.6%); palpitations, 1 (2.6%); renal colic, 1 (2.6%) | G2: 5.69 (1.29) | G2: 4.15 (1.24) (P = NR) | | | G2: 55.14 (1.3) (42–76) | G2: NR (P = NR)
| | | | | | | Funding: | (P = NS) | Diff between groups (P = NR) | | | (P = NS) | Diff between groups
| | | | | | | Roche | | Diff between groups in change over time (P = NS) | | | | Diff between groups (P = NR)
| | | | | | | | BITE-Sx, mean (SE) (range): | BITE-Sx, mean (SE): | | | BMI, kg/m^2^ (SE) (range):
| | | | | | | | G1: 24.19 (0.56) (15–28) | G1: 22.46 (0.93) (P = NR) | | | G1: 20.35 (0.43) (17–26)
| | | | | | | | G2: 24.08 (0.64) (15–28) | G2: 21.86 (0.83) (P = NR) | | | G2: 20.49 (0.41) (17–26)
| | | | | | | | (P = NS) | Diff between groups (P = NR) | | | (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | BITE-Severity, mean (SE) (range): | BITE-Severity, mean (SE):
| | | | | | | | G1: 11.69 (0.78) (3–20) | G1: 9.26 (0.56) (P = NR)
| | | | | | | | G2: 12.43 (0.80) (3–31) | G2: 9.43 (0.81) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDI mean (SE): | EDI mean (SE):
| | | | | | | | G1: 98.4 (6.3) | G1: 87.6 (6.7) (P = NR)
| | | | | | | | G2: 83.4 (6.3) | G2: 66.0 (6.1) (P = NR)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | TFEQ-1, restriction, mean (SE): | TFEQ-1, restriction, mean (SE):
| | | | | | | | G1: 13.32 (0.82) | G1: 13.04 (0.86) (P = NR)
| | | | | | | | G2: 13.04 (0.81) | G2: 13.72 (0.94) (P = NR)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | TFEQ-2, disinhibition, mean (SE): | TFEQ-2, disinhibition, mean (SE):
| | | | | | | | G1: 12.92 (0.37) | G1: 12.56 (0.48) (P = NR)
| | | | | | | | G2: 11.95 (0.51) | G2: 10.95 (0.56) (P = NR)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | TFEQ-3, hunger, mean (SE): | TFEQ-3, hunger, mean (SE):
| | | | | | | | G1: 10.28 (0.60) | G1: 9.84 (0.71) (P = NR)
| | | | | | | | G2: 8.22 (0.79) | G2: 8.22 (0.83) (P = NR)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | One capsule (4 mg of drug or placebo) whenever urge to binge-eat or vomit. Should first try to restrain themselves for 30 min. If urges constant or not clearly defined, take doses 30 minutes before eating. Up to 6 doses per day, could alter timing to max perceived effect for 4 wks. | Repeated measures analysis of variance (RM-ANOVA) with Huynh-Feldt corrections for sig. levels. Between-group effects examined using contrast analyses. To control for diff in groups in baseline values, data subjected to an ANCOVA with values during the single-blind placebo wk entered as covariates. | Score: | Binge-purge episodes in baseline wk for total sample, mean (SD): | Binge/vomit frequency during 4 ^ th ^ wk, mean (SD): | NR | NR | BMI, kg/m ^ 2 ^ , mean (SD):
Faris, et al., 2000 | RCT investigating use of ondansetron for participants with severe BN | G1: Ondansetron (N = 14) | Total: 29.1 (6) | Females, aged 18 or older not receiving any tx, bingeing followed by self-induced vomiting a min of 7 times a wk for at least 6 mos with a definite feeling of lack of control over the behavior, not engaged in other methods of purging, such as laxative or diuretic use, more than twice per wk in the past mo (more stringent than DSM IV BN criteria), BMI:17.5–23.5 kg/m^2^, normal blood counts, electrolyte concentrations, liver function tests, electrocardiograms and physical examinations, not pregnant, no serious diagnosed medical condition, not suicidal or psychotic, no current or previous dx of schizophrenia or bipolar disorder, no problem with drug or alcohol abuse in the 6 mos prior to study initiation, had not taken any psychoactive meds in 6 wks before study began. | Maintains daily meal pattern record, research assistants contacted participants to create backup of same info, met once a wk with a psychiatrist to evaluate compliance and any side effects. | | Good | 16.5 (7) | G1: 6.5 (3.9) (P = NR) | | | Total sample: 21.6 (2.5)
Setting: | | G2: Placebo (N = 12) | Sex: | Exclusion: | | | Intent to treat: | During single-blind placebo wk, coupled binge-eating and vomiting episodes/a wk, mean (SD): | G2: 13.2 (11.6) (P = NR)
Outpatient setting, Dept of Psychiatry, U of Minnesota, Minneapolis, MN, USA | | Enrollment: | Female: 100% | Those who developed psychiatric or physical symptoms requiring medical tx | | | Yes | G1: 12.8 (5.0) | Diff between groups (P < 0.0001)
Enrollment period: | | - 43 screened; - 29 selected for initial assessment; - 28 completed baseline study; - 26 completed single blind placebo wk and randomized; - 25 completed tx | Race/ethnicityd: | | | | Blinding: | G2: 13.4 (9.9) | Diff between groups in change over time (P < 0.001)
NR | | | NR | | | | Double | (P = NR) | G1 better than G2
| | | Duration of BN (SD): | | | | Adverse events: | Number of “normal meals” consumed | Number of “normal meals” consumed: | | | Wt, at single blind placebo wk, kg, mean | Wt after wk 4, kg, mean:
| | | Total: 11.8 yrs (6.6) | | | | Participants evaluated but none reported. One patient dropped out due to injury but no information about injury provided. | G1: NR | G1: NR (P = 0.03) | | | G1: 60.3 | G1: 60.4 (P = NR)
| | | | | | | Funding: | G2: NR | G2: NR (P = NR) | | | G2: 60.1 | G2: 60.8 (P = NR)
| | | | | | | Mark A Nugent Research Foundation | (P = NR) | Diff between groups (P = NR) | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.03) | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | G1 better than G2
| | | | | | | | Time spent engaging in bulimic behaviors: | Time spent engaging in bulimic behaviors:
| | | | | | | | G1: NR | G1: NR (P = 0.04)
| | | | | | | | G2: NR | G2: NR
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | G1 less than G2
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Identical capsules containing either 50 mg of fluvoxamine or a lactose filler as a replacement; started at one capsule in the morning about 3 wks before the end of inpatient tx; stepwise increases every 3–4 days; usual dosage increased by one capsule and if tolerated, dose increased to a max of 300 mg of fluvoxamine by end of tx. Participants in placebo group received an avg of 4.4 capsules a day. Avg dose 182 ± 4.1mg. | Participants who took meds in the off-meds phase included in the examination but excluded from analyses related to the off-meds phase. Repeated measures MANOVA's for diffs between placebo and meds groups. ANOVA's for main diffs across all three tx phases. Chi-square tests for nonparametric data. | Score: | Values obtained immediately before discharge. | Values obtained 12 wks post-discharge. | Global assessment, mean: | Global assessment, mean: | BMI, kg/m ^ 2 ^ , mean: | BMI, kg/m ^ 2 ^ , mean:
Fichter et al., 1996 | Compare fluvoxamine with placebo in maintaining improvement and preventing relapse in bulimic symptoms after tx with psychotherapy. | G1 = Fluvoxamine group | G1: 25.2 (4.9) | Between 18 and 50, DSM III-R BN of at least 6 mos duration prior to admission, body wt between 85% and 125% of IBW, inpatient improvements of 4 points on clinical global impression - severity of illness scale during inpatient admission; 5 or fewer binges in the last wk of inpatient tx. | | | Fair | Urge to binge: binge frequency previous wk, mean: | Urge to binge: binge frequency previous wk, mean: | G1: 3.0 | G1: 3.3 (P = NR) | G1: 20.7 | G1: 21.4 (P = NR)
Companion article: | | G2 = Placebo group | G2: 23.7 (5.1) | Meds very rarely or in very low doses (i.e., low doses of psychoactive substances on a herbal basis or homeopathic dosages; up to 1 gm per night of chloralhydrate for sleep; 50 mg or less of isopromethazine; 1 mg in injection form of fluspirilene for crisis; 50 mg or less of amitriptyline; normal dose of benzodiazepines for less than 5 days or when taken in low or avg dosage, i.e., about 5 mg of diazepam a day). | | | Intent to treat: | G1: 0.9 | G1: 1.9 (P = NR) | G2: 2.8 | G2: 4.1 (P = NR) | G2: 20.2 | G2: 20.7 (P = NR)
Fichter et al., 1997 | | Enrollment: | (P = NS) | Exclusion: | | | Yes | G2: 1.0 | G2: 3.7 (P = NR) | (P = NR) | Diff over time (P < 0.001) | (P = NS) | Diff over time (P < 0.001)
Setting: | | - 257 patients admitted to inpatient unit between December 1989 and March 1992; - 81 fulfilled inclusion criteria and randomly assigned to meds or placebo at admission to inpatient program.; - 72 patients who had responded sufficiently to inpatient tx (9 were excluded as they were bingeing > 5 times/wk) began the tx. | Sex: | Pregnant or lactating, serious medial conditions, psychosis or acute suicidal ideation, seizures, insulin-dependent diabetes or if used other psychoactive meds, appetite suppressants or other relevant meds within 2 wks prior to entering meds part of study. Avg or high dose of concurrent psychoactive meds over more than 4 days during the study also excluded. | | | Blinding: | (P = NR) | Diff over time (P < 0.001) | | Diff between groups (P = NS) | | Diff between groups (P = NS)
Roseneck Hospital, Prien, Germany | | The study had three phases; inpatient tx phase, followed by a maintenance/outpatient tx phase and lastly, a 4-wk off-meds/placebo phase. | Female: 100% | | | | Double | | Diff between groups (P = NS) | | Diff between groups in change over time (P < 0.01) | | Diff between groups in change over time (P = NS)
Enrollment period: | | | Race/ethnicity: | | | | Adverse events: | | Diff between groups in change over time (P = NS) | | G1 better than G2
December 1989 to March 1992 | | | NR | | | | 1 patient in G2 had to be admitted to the hospital. 1 patient from G2 complained of side effects. 8 patients from G1 dropped out due to side effects. Common side effects included nausea, dizziness and drowsiness (more common in the patients receiving fluvoxamine). | SIAB-Bulimia, mean: | SIAB-Bulimia, mean:
| | | Age at onset, yrs, mean (SD): | | | | Funding: | G1: 1.2 | G1: 1.8 (P = NR)
| | | G1: 19 (3) | | | | NR | G2: 0.8 | G2: 2.2 (P = NR)
| | | G2: 19 (4) | | | | | (P = NR) | Diff over time (P < 0.001)
| | | Binge episodes in the mo prior to admission, mean (SD): | | | | | | Diff between groups (P = NS)
| | | G1: 16 (15) | | | | | | Diff between groups in change over time (P = NS)
| | | G2: 15 (15) | | | | | SIAB-total, mean: | SIAB-total, mean:
| | | Marital status, never married: | | | | | G1: 1.3 | G1: 1.6 (P = NR)
| | | G1: 81% | | | | | G2: 1.1 | G2: 1.7 (P = NR)
| | | G2: 86% | | | | | (P = NR) | Diff over time (P < 0.001)
| | | Hx of depression: | | | | | | Diff between groups (P = NS)
| | | G1: 43% | | | | | | Diff between groups in change over time (P < 0.05)
| | | G2: 49% | | | | | | G1 better than G2
| | | Hx of anxiety disorder: | | | | | EDI-total score, mean: | EDI-total score, mean:
| | | G1: 41% | | | | | G1: 0.73 | G1: 0.78 (P = NR)
| | | G2: 31% | | | | | G2: 0.60 | G2: 0.86 (P = NR)
| | | Hx of obesity: | | | | | (P = NR) | Diff over time (P < 0.01)
| | | G1: 14% | | | | | | Diff between groups (P = NS)
| | | G2: 11% | | | | | | Diff between groups in change over time (P = NS)
| | | Hx of alcohol abuse: | | | | | EDI-Bulimia, mean: | EDI-Bulimia, mean:
| | | G1: 19% | | | | | G1: 0.47 | G1: 0.40 (P = NR)
| | | G2: 17% | | | | | G2: 0.22 | G2: 0.61 (P = NR)
| | | Hx of suicide attempts: | | | | | (P = NR) | Diff over time (P < 0.05)
| | | G1: 27% | | | | | | Diff between groups (P = NS)
| | | G2: 23% | | | | | | Diff between groups in change over time (P < 0.01)
| | | | | | | | | G1 better than G2
| | | | | | | | SIAB-expert rating: fasting, mean: | SIAB-expert rating: fasting, mean:
| | | | | | | | G1: 0.9 | G1: 0.7 (P = NR)
| | | | | | | | G2: 1.0 | G2: 1.4 (P = NR)
| | | | | | | | (P = NR) | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | G1 better than G2
| | | | | | | | SIAB-expert rating: qualitative food reduction, mean N: | SIAB-expert rating: qualitative food reduction, mean:
| | | | | | | | G1: 1.2 | G1: 0.8 (P = NR)
| | | | | | | | G2: 0.9 | G2: 1.0 (P = NR)
| | | | | | | | (P = NR) | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | SIAB-expert rating: vomiting, mean: | SIAB-expert rating: vomiting, mean:
| | | | | | | | G1: 1.3 | G1: 1.8 (P = NR)
| | | | | | | | G2: 0.6 | G2: 2.0 (P = NR)
| | | | | | | | (P = NR) | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | G1 better than G2
| | | | | | | | Fear to lose control over eating behavior, mean: | Fear to lose control over eating behavior, mean:
| | | | | | | | G1: 97 | G1: 98 (P = NR)
| | | | | | | | G2: 97 | G2: 187 (P = NR)
| | | | | | | | (P = NR) | Diff over time (P < 0.01)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P < 0.01)
| | | | | | | | | G1 better than G2
| | | | | | | | Urge to binge in last 7 days in VAS, mean: | Urge to binge in last 7 days in VAS, mean:
| | | | | | | | G1: 138 | G1: 147 (P = NR)
| | | | | | | | G2: 118 | G2: 195 (P = NR)
| | | | | | | | (P = NR) | Diff over time (P < 0.01)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | G1 better than G2
| | | | | | | | | Severity of Eating Disorderpatient rating:
| | | | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | Severity of Eating Disorder - expert rating:
| | | | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | Figure Consciousness and Body Image:
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | “Deterioration” (increase) in severity of bulimic symptoms:
| | | | | | | | | G1: 10% (P = NR)
| | | | | | | | | G2: 46% (P = NR)
| | | | | | | | | “Deterioration” (increase) in number of binges in previous wk:
| | | | | | | | | G1: 111% (P = NR)
| | | | | | | | | G2: 270% (P = NR)
| | | | | | | | | Abstinence from bingeing:
| | | | | | | | | G1: NR
| | | | | | | | | G2: NR
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G1 better than G2
| | | | | | | | | Abstinence from vomiting:
| | | | | | | | | G1: NR
| | | | | | | | | G2: NR
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | “Deterioration” (increase) in SIAB-bulimia:
| | | | | | | | | G1: 50% (P = NR)
| | | | | | | | | G2: 175% (P = NR)
| | | | | | | | | Relapse (defined as score of 5 or more on CGI severity) before end of the relapse prevention phase:
| | | | | | | | | G1: 8.1% (P = NR)
| | | | | | | | | G2: 31.4% (P = NR)
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Patients dispensed identical capsules containing either 50 mg of fluvoxamine or a lactose filler as a replacement; started at one capsule in the morning about 3 wks before end of inpatient tx; stepwise increases every 3–4 days; usual dosage increased by one capsule and if tolerated, increased to a max of 300 mg of fluvoxamine by end of tx. Placebo group received an avg of 4.4 capsules a day. Avg dose 182 ± 4.1mg. | MANOVA's for the relapse prevention phase and two factorial ANOVA's for each of the 3 phases (only completer for last phase). Mann Whitney U tests for examining relapses. T-tests were used to look at diffs in side effect duration and severity and use of subsequent tx. | Score: | Values obtained immediately before discharge. | Values obtained 12 wks post-discharge.
Fichter et al., 1997 | Compare fluvoxamine with placebo on depression, anxiety and other areas of psychopathology among individuals with BN after inpatient tx with psychotherapy. | G1 = Fluvoxamine group | G1: 25.2 (4.9) | Years of age between 18 and 50, DSM III-R BN of at least 6 mos duration prior to admission, body wt between 85% and 125% of IBW, inpatient improvements of 4 points on clinical global impression - severity of illness scale during inpatient admission; 5 or fewer binges in the last wk of inpatient tx. | | | Fair | Urge to binge: binge frequency previous wk, mean: | Urge to binge: binge frequency previous wk, mean: | CGI Severity, mean: | CGI Severity, mean: | BMI, kg/m ^ 2 ^ , mean: | BMI, kg/m ^ 2 ^ , mean:
Companion article: | | G2 = Placebo group | G2: 23.7 (5.1) | Meds very rarely or in very low doses (i.e., low doses of psychoactive substances on a herbal basis or homeopathic dosages; up to 1 gm per night of chloralhydrate for sleep; 50 mg or less of isopromethazine; 1 mg in injection form of fluspirilene for crisis; 50 mg or less of amitriptyline; normal dose of benzodiazepines for less than 5 days or when taken in low or avg dosage, i.e., about 5 mg of diazepam a day). | | | Intent to treat: | G1: 0.9 | G1: 1.9 (P = NR) | G1: 3.1 | G1: 3.3 (P = NR) | G1: 20.7 | G1: 21.4 (P = NR)
Fichter et al., 1996 | | Enrollment: | (P = NS) | Exclusion: | | | Yes | G2: 1.0 | G2: 3.7 (P = NR) | G2: 3.0 | G2: 3.7 (P = NR) | G2: 20.2 | G2: 20.7 (P = NR)
Setting: | | - 257 patients admitted to inpatient unit between December 1989 and March 1992; - 81 fulfilled inclusion criteria and were randomly assigned to meds or placebo at admission to the inpatient program.; - 72 patients who responded sufficiently to inpatient tx and began the tx. (9 were excluded as they were bingeing > 5 times/wk); - Out of 72 patients who began tx, 24 dropped out or excluded because of low fluvoxamine levels. | Sex: | Pregnant or lactating, serious medial conditions, psychosis or acute suicidal ideation, hx of seizures, insulin-dependent diabetes or if used other psychoactive meds, appetite suppressants or other relevant meds within 2 wks prior to entering meds part of study. Avg or high dose of concurrent psychoactive meds over more than 4 days during the study also excluded. | | | Blinding: | (P = NR) | Diff over time (P < 0.001) | (P = NS) | Diff over time (P < 0.001) | (P = NS) | Diff over time (P < 0.001)
Roseneck Hospital, Prien, Germany | | The study had three phases; inpatient tx phase, followed by a maintenance/outpatient tx phase and lastly, a 4-wk off-meds/placebo phase. | Female: 100% | | | | Double | | Diff between groups (P = NS) | | Diff between groups (P = NS) | | Diff between groups (P = NS)
Enrollment period: | | | Race/ethnicity: | | | | Adverse events: | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P < 0.05) | | Diff between groups in change over time (P = NS)
December 1989 to March 1992 | | | NR | | | | 1 patient in G2 had to be admitted to the hospital. 1 patient from G2 complained of side effects. 8 patients from G1 dropped out due to side effects. Common side effects included nausea, dizziness and drowsiness (more common in fluvoxamine group). | | | | G1 better than G2
| | | Age at onset, yrs, mean (SD): | | | | Funding: | SIAB-Bulimia, mean: | SIAB-Bulimia, mean: | HDRS, mean: | HDRS, mean:
| | | G1: 19 (3) | | | | | G1: 1.2 | G1: 1.8 (P = NR) | G1: 12.3 | G1: 13.2 (P = NR)
| | | G2: 19 (4) | | | | NR | G2: 0.8 | G2: 2.2 (P = NR) | G2: 10.1 | G2: 15.0 (P = NR)
| | | Binge episodes in the mo prior to admission, mean (SD): | | | | | (P = NR) | Diff over time (P < 0.001) | (P = NS) | Diff over time (P < 0.05)
| | | G1: 16 (15) | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | G2: 15 (15) | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | Marital status, never married: | | | | | SIAB-total, mean: | SIAB-total, mean: | Hopkins Symptom Checklist Depression, mean: | Hopkins Symptom Checklist depression, mean:
| | | G1: 81% | | | | | G1: 1.3 | G1: 1.6 (P = NR) | G1: 1.9 | G1: 1.9 (P = NR)
| | | G2: 86% | | | | | G2: 1.1 | G2: 1.7 (P = NR) | G2: 1.7 | G2: 2.0 (P = NR)
| | | Hx of depression: | | | | | (P = NR) | Diff over time (P < 0.001) | (P = NS) | Diff over time (P < 0.05)
| | | G1: 43% | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | G2: 49% | | | | | | Diff between groups in change over time (P < 0.05) | | Diff between groups in change over time (P = NS)
| | | Hx of anxiety disorder: | | | | | | G1 better than G2
| | | G1: 41% | | | | | EDI-total score, mean: | EDI-total score, mean: | Hopkins Symptom Checklist Anxiety, mean: | Hopkins Symptom Checklist Anxiety, mean:
| | | G2: 31% | | | | | G1: 0.73 | G1: 0.78 (P = NR) | G1: 1.7 | G1: 1.7 (P = NR)
| | | Hx of obesity: | | | | | G2: 0.60 | G2: 0.86 (P = NR) | G2: 1.8 | G2: 1.9 (P = NR)
| | | G1: 14% | | | | | (P = NR) | Diff over time (P < 0.01) | (P = NS) | Diff over time (P = NS)
| | | G2: 11% | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | Hx of alcohol abuse: | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | G1: 19% | | | | | EDI-Bulimia, mean: | EDI-Bulimia, mean: | Hopkins Symptom Checklist Obsessions-Compulsions, mean: | Hopkins Symptom Checklist Obsessions-Compulsions, mean:
| | | G2: 17% | | | | | G1: 0.47 | G1: 0.40 (P = NR) | G1: 1.8 | G1: 1.8 (P = NR)
| | | Hx of suicide attempts: | | | | | G2: 0.22 | G2: 0.61 (P = NR) | G2: 1.7 | G2: 2.1 (P = NR)
| | | G1: 27% | | | | | (P = NR) | Diff over time (P < 0.05) | (P = NS) | Diff over time (P = NS)
| | | G2: 23% | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P < 0.01) | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | G1 better than G2 | | G1 better than G2
| | | | | | | | SIAB-expert rating: fasting, mean: | SIAB-expert rating: fasting, mean:
| | | | | | | | G1: 0.9 | G1: 0.7 (P = NR)
| | | | | | | | G2: 1.0 | G2: 1.4 (P = NR)
| | | | | | | | (P = NR) | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | G1 better than G2
| | | | | | | | SIAB-expert rating: qualitative food reduction, mean N: | SIAB-expert rating: qualitative food reduction, mean:
| | | | | | | | G1: 1.2 | G1: 0.8 (P = NR)
| | | | | | | | G2: 0.9 | G2: 1.0 (P = NR)
| | | | | | | | (P = NR) | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | SIAB-expert rating: vomiting, mean: | SIAB-expert rating: vomiting, mean:
| | | | | | | | G1: 1.3 | G1: 1.8 (P = NR)
| | | | | | | | G2: 0.6 | G2: 2.0 (P = NR)
| | | | | | | | (P = NR) | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | G1 better than G2
| | | | | | | | Fear to lose control over eating behavior, mean: | Fear to lose control over eating behavior, mean:
| | | | | | | | G1: 97 | G1: 98 (P = NR)
| | | | | | | | G2: 97 | G2: 187 (P = NR)
| | | | | | | | (P = NR) | Diff over time (P < 0.01)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P < 0.01)
| | | | | | | | | G1 better than G2
| | | | | | | | Urge to binge in last 7 days in VAS, mean: | Urge to binge in last 7 days in VAS, mean:
| | | | | | | | G1: 138 | G1: 147 (P = NR)
| | | | | | | | G2: 118 | G2: 195 (P = NR)
| | | | | | | | (P = NR) | Diff over time (P < 0.01)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | G1 better than G2
| | | | | | | | | Severity of Eating Disorderpatient rating:
| | | | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | Severity of Eating Disorder - expert rating:
| | | | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | Figure Consciousness and Body Image:
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | “Deterioration” (increase) in severity of bulimic symptoms:
| | | | | | | | | G1: 10% (P = NR)
| | | | | | | | | G2: 46% (P = NR)
| | | | | | | | | “Deterioration” (increase) in number of binges in previous wk:
| | | | | | | | | G1: 111% (P = NR)
| | | | | | | | | G2: 270% (P = NR)
| | | | | | | | | Abstinence from bingeing:
| | | | | | | | | G1: NR
| | | | | | | | | G2: NR
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G1 better than G2
| | | | | | | | | Abstinence from vomiting:
| | | | | | | | | G1: NR
| | | | | | | | | G2: NR
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | “Deterioration” (increase) in SIAB-bulimia:
| | | | | | | | | G1: 50% (P = NR)
| | | | | | | | | G2: 175% (P = NR)
| | | | | | | | | Relapse (defined as score of 5 or more on CGI severity) before end of the relapse prevention phase:
| | | | | | | | | G1: 8.1% (P = NR)
| | | | | | | | | G2: 31.4% (P = NR)
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | In 10 balanced blocks of 4, 40 patients with BN randomly assigned to 60mg fluoxetine or placebo; in addition to meds, all participants continued in intensive inpatient care—a broad spectrum, behavioral tx program. | Repeated-measures ANOVA | Score: | EDI, Bulimia, mean (SD) | End of tx: | HAM-D, total score, mean (SD): | End of tx: | Wt, kg, mean (SD): | Wt, kg, mean (SD):
Fichter et al., 1991 | To assess the efficacy of fluoxetine (60mg) versus placebo in the tx of individuals with BN already receiving intensive inpatient behavioral psychotherapy. | G1: Fluoxetine (N = 20) | G1: 26.5 (NR) | Dx of BN (DSM III-R); inpatient status | After a 3–7 day washout period, received a 60 mg/day dose of fluoxetine or placebo for 35 days; no other psychotropic meds given, except for chloralhydrate and benzodiazepines, if necessary. | Self-report measures regarding and clinically administered ratings, and biometric measures made one wk before tx start, and on days, 7, 14, 21, 28, 35. | Good | G1: 10.2 (5.3) | EDI, Bulimia, mean (SD) | G1: 13.3 (5.6) | HAM-D, total score, mean (SD): | G1: 56.8 (12.3) | G1: 55.3 (9.1) (P = NR)
Setting: | | G2: Placebo (N = 20) | G2: 24.6 (NR) | Exclusion: | | | Intent to treat: | G2: 9.9 (3.5) | G1: 3.0 (4.8) (P = NR) | G2: 14.1 (7.0) | G1: 8.3 (5.0) (P = NR) | G2: 54.7 (11.1) | G2: 55.0 (10.1) (P = NR)
Inpatient clinic; Klinik Roseneck, Prien, Germany | | Enrollment: | (P = NS) | Pregnancy; serious suicidal risks, medical risks or disorders; schizophrenia, hx of seizures or drug/alcohol addiction; PreTx with long-acting neuroleptics | | | Yes | (P = NS) | G2: 4.0 (4.8) (P = NR) | (P = NS) | G2: 11.1 (7.4) (P = NR) | (P = NS) | Diff over time (P = 0.05)
Enrollment period: | | - 40 randomized; - 39 analyzed (G1: 19; G2: 20), with I exclusion; - 0 drop outs | Sex, N: | | | | Blinding: | | Diff over time (P = 0.001) | | Diff over time (P = NS) | | Diff between groups (P = NS)
NR | | | Female: 39 | | | | Double | | Diff between groups (P = NS) | | Diff between groups (P = NS) | | Diff between groups in change over time (P = NS)
| | | Male: 1 | | | | Adverse events: | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | Race/ethnicity: | | | | One patient excluded due to undetectable fluoxetine plasma levels at all measurement points; G1 reported sig more “trembling” than G2 (P = 0.02); No sig diffs observed for numbness, nausea, body tingling, "mind going blank, hot and cold spells, trouble getting breath, heart racing, pains in heart, nervousness or shaking, heartache or restlessness, trouble concentrating, anxiety, poor appetite, sweating, elevated systolic and diastolic blood pressure, elevated pulse rate, reduced white blood count, reduced hemoglobin, increased liver enzymes and creatinine, and changes in serum potassium. | EDI, Drive for thinness, mean,\ (SD) | EDI, Drive for thinness, mean (SD) | SCL-90, depression, mean (SD): | SCL-90, depression (SD):
| | | NR | | | | Funding: | G1: 12.3 (5.4) | G1: NR (P = NR) | G1: 1.7 (0.9) | G1: NR (P = NR)
| | | Age of onset of eating disorder, yrs, mean (SD): | | | | NR | G2: 11.0 (4.7) | G2: NR (P = NR) | G2: 1.8 (0.8) | G2: NR (P = NR)
| | | G1: 16.6 (NR) | | | | | (P = NS) | Diff over time (P = 0.001) | (P = NS) | Diff over time (P = NR)
| | | G2: 16.2 (NR) | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | (P = NS) | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | Hx of AN, N (%): | | | | | EDI, Total score, mean (SD): | EDI, Total score, mean (SD): | SCL-90, anxiety, mean (SD): | SCL-90, anxiety, mean (SD):
| | | G1: 10/20 (50%) | | | | | G1: 82.7 (32.5) | G1: NR (P = NR) | G1: 1.0 (0.8) | G1: NR (P = NR)
| | | G2: 10/20 (50%) | | | | | G2: 76.9 (28.9) | G2: NR (P = NR) | G2: 1.3 (1.0) | G2: NR (P = NR)
| | | (P = NS) | | | | | (P = NS) | Diff over time (P = 0.001) | (P = NS) | Diff over time (P = NS)
| | | Laxative abuse, past wk, N (%): | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | G1: 4/20 (30%) | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | G2: 1/20 (35%) | | | | | | EDI, Body Dissatisfaction, mean (SD):
| | | (P = NR) | | | | | | G1: NR (P = NR)
| | | | | | | | | G2: NR (P = NR)
| | | | | | | | | Diff over time (P = 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | SIAB-Global rating, mean (SD):
| | | | | | | | | G1: NR (P = NR)
| | | | | | | | | G2: NR (P = NR)
| | | | | | | | | Diff over time (P = 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Urge to binge, past wk, mean (SD): | Urge to binge, past wk, mean (SD):
| | | | | | | | G1: 2.51 (1.20) | G1: 1.37 (0.90) (P = NR)
| | | | | | | | G2: 2.64 (0.83) | G2: 1.54 (0.95) (P = NR)
| | | | | | | | (P = NS) | Diff over time (P = 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Binge attacks, past wk, mean (SD): | Binge attacks, past wk, mean (SD):
| | | | | | | | G1: 5.63 (9.10) | G1: 3.00 (4.77) (P = NR)
| | | | | | | | G2: 8.85 (7.99) | G2: 6.60 (6.94) (P = NR)
| | | | | | | | (P = NS) | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Anxiety, loss of control over eating (0–4), mean (SD): | Anxiety, loss of control over eating (0–4), mean (SD):
| | | | | | | | G1: 2.7 (1.4) | G1: NR (P = NR)
| | | | | | | | G2: 1.9 (1.0) | G2: NR (P = NR)
| | | | | | | | (P = 0.05) | Diff over time (P = 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | NR | Abstinence NR
| | | | | | | | | The following selected SIAB items were reported over time within both groups (means: NR): | | CGI-Severity of illness, mean (SD):
| | | | | | | | | - Compulsive eating behavior (P = NS); - Compulsive thoughts about eating(P = NS); - Ideal of slimness (P = 0.001); - Fasting (P = 0.001); - Body image disturbance (P = 0.05); - Induced vomiting (P = 0.01); - Laxative abuse (P = NS) | | G1: NR (P = NR)
| | | | | | | | | No sig diff between groups, or sig diff between groups in change over time were reported for any of these items | | G2: NR (P = NR)
| | | | | | | | | | | Diff over time (P = 0.001)
| | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | | | CGI-Change over time, mean (SD):
| | | | | | | | | | | G1: NR (P = NR)
| | | | | | | | | | | G2: NR (P = NR)
| | | | | | | | | | | Diff over time (P = 0.001)
| | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | | | CGI-Therapy effectiveness, mean (SD):
| | | | | | | | | | | G1: NR (P = NR)
| | | | | | | | | | | G2: NR (P = NR)
| | | | | | | | | | | Diff over time (P = 0.001)
| | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | | | CGI-Risk index, mean (SD):
| | | | | | | | | | | G1: NR (P = NR)
| | | | | | | | | | | G2: NR (P = NR)
| | | | | | | | | | | Diff over time (P = 0.001)
| | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | 1 wk of single-blind placebo admin, followed by random assignment to placebo, 20 mg fluoxetine, or 60 mg of fluoxetine for 8 wks. | ANOVAs on rank transformed data for continuous efficacy and safety variables; Pairwise comparisons using Fisher's least sig diff; Cochran-Mantel-Haenszel mean score test for bulimic response data; Pearson's X^2^ tests for subject dispositional and adverse event data; Spearman's rank correlation coefficients for efficacy versus drug plasma concentration correlations; multiple logistic regressions for predicting response to fluoxetine. | Score: | Binge episodes/wk, mean (SD): | Median % reduction in binges/wk: | HDRS total score, mean (SD): | Change HDRS total score, median: | Wt, kg, mean (SD): | Change in wt, kg, median:
Fluoxetine BN Collaborative Study Group, 1992 | To compare the efficacy and safety of two doses of fluoxetine in the tx of BN | G1: Placebo (N = 129) | G1: 27.7 (8.0) | Female, met DSM III-R criteria for BN; ≥ 3 binge eating episodes per wk for at least 6 mos; age 18+; between 85%-130% of midpoint of IBW for ht. | Participants seen wkly for recording of wt, blood pressure, resting pulse, and oral temperature. Administered HDRS, EDI, EAT, and 2 visual analog scales for measuring carbohydrate craving and bulimic intensity. Subjects recorded number of daily binge eating and purging episodes in diary, which were totaled at wkly visit. Clinicians subjectively rated subject's global improvement during each visit. Med compliance assessed by capsule count (# dispensed # returned). | | Fair | G1: 11.0 (8.0) | G1: 33% (P = NR) | G1: 11.8 (7.7) | G1: -3.0 (P = NR) | G1: 61.1 (9.8) | G1: 0.0 (P = NR)
Comparison articles: | | G2: Fluoxetine 20 mg (N = 129) | G2: 27.4 (7.2) | Exclusion: | Tx responders: at least 50% improvement in binge-eating and vomiting frequency. Med non-compliance: taking < 80% of recommended dosage by endpoint. | | Intent to treat: | G2: 8.0 (5.0) | G2: 45% (P = NR) | G2: 11.9 (7.3) | G2: -4.0 (P = NR) | G2: 60.3 (10.9) | G2: -0.5 (P = NR)
Goldstein, 1995 and Goldstein, 1999 | | G3: Fluoxetine 60 mg (N = 129) | G3: 26.4 (6.2) | Pregnant or lactating; serious medical illness; psychosis; acute suicidal ideation; initial serum potassium level < 3.0 mmol/L; used psychoactive meds 2 wks prior to enrollment; initiated some other form of tx for BN (e.g., psychotherapy or behavior therapy) 1 mo prior to enrollment; 1 wk placebo responders (i.e., 75% improvement or had < 3 bulimic episodes per wk). | | | Analyses not performed on initial randomized sample of 387 but on those who returned for at least 1 visit after randomization (N = 382). | G3: 11.0 (10.0) | G3: 67% (P = NR) | G3: 11.9 (7.3) | G3: -5.0 (P = NR) | G3: 60.4 (9.2) | G3: -1.6 (P = NR)
Setting: | | Enrollment: | (P = NS) | | | | Blinding: | (P = NR) | Diff between groups (P ≤ 0.003) | (P = NS) | Diff between groups (P = 0.033) | (P = NS) | Diff between groups (P = 0.013)
13 Outpatient centers in the U.S. and Canada | | - 442 screened; - 387 randomized (129 assigned to each group); - 270 after 8 wks | Sex: | | | | Double | | G3 better than G2 and G1 | | G3 better than G1 | | G3 and G2 better than G1
Enrollment period: | | | Female: 100% | | | | Adverse events: | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
NR | | | Race/ethnicity: | | | | Insomnia (P < 0.001) | | Wkly median % change in binges/wk (wks 1–7): | | % med non-compliance at 8 wks:
| | | White: | | | | Nausea (P = 0.021) | | G1, G2, G3 data shown in figure | | G1: 16.3%
| | | G1: 98% | | | | Asthenia (P = 0.039) | | Diff between groups (P < 0.005) | | G2: 13.2%
| | | G2: 95% | | | | Tremor (P < 0.001) | | G3 better than G1 | | G3: 20.2%
| | | G3: 97% | | | | Sweating (P = 0.036) | | Diff between groups in change over time (P = NR) | | (P = NS)
| | | (P = NS) | | | | Urinary frequency (P = 0.012) | | % ≥ 50% improved in binges/wk at end of tx:
| | | BMI, kg/m ^ 2 ^ , mean (SD): | | | | Palpitation (P = 0.017) | | G1: 43% (P = NR)
| | | G1: 22.6 (3.3) | | | | Yawn (P = 0.017) | | G2: 49% (P = NR)
| | | G2: 22.7 (4.2) | | | | Mydriasis (P = 0.018) | | G3: 63% (P = NR)
| | | G3: 22.4 (3.2) | | | | Vasodilation (P = 0.029) | | Diff between groups (P ≤ 0.003)
| | | (P = NS) | | | | All events greater in the active vs placebo groups. No sig diff among groups for adverse events being the reason why participants discontinued the study. | | G3 better than G1 and G2
| | | BN behaviors (self-report): | | | | Funding: | | Diff between group in change over time (P = NR)
| | | Vomiting (83%) | | | | Eli Lilly and Company | | Binge Abstinence (full remission):
| | | Laxative abuse (60%) | | | | | | G1, G2, G3 shown in figure
| | | Diuretic abuse (22%) | | | | | | Diff between groups (P = NR)
| | | Fasting (13%) | | | | | Vomiting episodes/wk, mean (SD): | Median % reduction vomiting/wk:
| | | Strict dieting or exercising (27%) | | | | | G1: 11.0 (14.0) | G1: 5% (P = NR)
| | | | | | | | G2: 9.0 (10.0) | G2: 29% (P = NR)
| | | | | | | | G3: 11.0 (14.0) | G3: 56% (P = NR)
| | | | | | | | (P = NR) | Diff between groups (P ≤ 0.04)
| | | | | | | | | G3 and G2 better than G1 (P = 0.003)
| | | | | | | | | G3 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Wkly median % change in vomiting/wk frequency (wks 1–7):
| | | | | | | | | G1, G2, G3 shown in figure
| | | | | | | | | Diff between groups (P < 0.005)
| | | | | | | | | G3 better than G1
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | % ≥ 50% improved in tx vomiting/wk at end of tx:
| | | | | | | | | G1: 26% (P = NR)
| | | | | | | | | G2: 45% (P = NR)
| | | | | | | | | G3: 57% (P = NR)
| | | | | | | | | Diff between groups (P = 0.021)
| | | | | | | | | G3 and G2 better than G1 (P = 0.011)
| | | | | | | | | G3 better than G2
| | | | | | | | | Vomiting Abstinence (full remission):
| | | | | | | | | G1, G2, G3 shown in figure
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | EAT total score, mean (SD): | Change in EAT Total Scale, median:
| | | | | | | | G1: 35.0 (13.3) | G1: -4.0 (P = NR)
| | | | | | | | G2: 32.5 (12.4) | G2: -8.5 (P = NR)
| | | | | | | | G3: 31.5 (12.5) | G3: -8.5 (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = 0.006)
| | | | | | | | | G3 and G2 better than G1
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Change in EAT diet preoccupation, median:
| | | | | | | | | G1: -2.0 (P = NR)
| | | | | | | | | G2: -5.0 (P = NR)
| | | | | | | | | G3: -4.0 (P = NR)
| | | | | | | | | Diff between groups (P = 0.011)
| | | | | | | | | G3 and G2 better than G1
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Change in EAT food preoccupation, median:
| | | | | | | | | G1: -2.0 (P = NR)
| | | | | | | | | G2: -4.0 (P = NR)
| | | | | | | | | G3: -5.0 (P = NR)
| | | | | | | | | Diff between groups (P = 0.016)
| | | | | | | | | G3 and G2 better than G1
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Change in EAT oral control, median
| | | | | | | | | G1: 0.0 (P = NR)
| | | | | | | | | G2: 0.0 (P = NR)
| | | | | | | | | G3: 0.0 (P = NR)
| | | | | | | | | Diff between groups (P = 0.005)
| | | | | | | | | G3 better than G1
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Change EDI drive for thinness, median:
| | | | | | | | | G1: -1.5 (P = NR)
| | | | | | | | | G2: -2.0 (P = NR)
| | | | | | | | | G3: -3.0 (P = NR)
| | | | | | | | | Diff between groups (P = 0.008)
| | | | | | | | | G3 better than G1
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Change EDI Bulimia, median:
| | | | | | | | | G1: -3.0 (P = NR)
| | | | | | | | | G2: -4.0 (P = NR)
| | | | | | | | | G3: -5.0 (P = NR)
| | | | | | | | | Diff between groups (P = 0.003)
| | | | | | | | | G3 better than G1
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Change EDI body dissatisfaction, median:
| | | | | | | | | G1: 0.0 (P = NR)
| | | | | | | | | G2: -2.0 (P = NR)
| | | | | | | | | G3: -3.0 (P = NR)
| | | | | | | | | Diff between groups (P = 0.027)
| | | | | | | | | G3 and G2 better than G1
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Bulimic intensity (SD): | Change bulimic intensity, median:
| | | | | | | | G1: 7.2 (2.0) | G1: -1.0 (P = NR)
| | | | | | | | G2: 6.8 (1.8) | G2: -2.0 (P = NR)
| | | | | | | | G3: 6.6 (2.1) | G3: -2.0 (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = 0.035)
| | | | | | | | | G3 and G2 better than G1
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Carbohydrate craving (SD): | Change carbohydrate craving, median:
| | | | | | | | G1: 7.0 (2.3) | G1: -1.0 (P = NR)
| | | | | | | | G2: 6.8 (2.4) | G2: -2.0 (P = NR)
| | | | | | | | G3: 6.7 (2.4) | G3: -2.0 (P = NR)
| | | | | | | | (P = NS) | Diff over time between (P = 0.017)
| | | | | | | | | G3 and G2 better than G1
| | | | | | | | | Diff between groups in change over time (P = NR)
Author, year: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | 1 wk drug-free pre-screen period followed by 2 wks of single-blind placebo run-in administration, followed by random assignment (1:3) to placebo or 60 mg of fluoxetine for 16 wks. | For each RCT, subjects stratified by median depression scores on the HRSD (i.e.12). Baseline dx of current depression or hx of depression as assessed via patient history also used to stratify subjects for another set of analyses per RCT. | Score: | Baseline data reported in companion articles | For 8-wk trial stratified by median HRSD: | | None reported | | None reported
Goldstein et al., 1999 | Retrospective analyses of data obtained from two previous RCTs assessing the effectiveness and safety of fluoxetine in treating the primary and associated symptoms of BN. This study aimed to evaluate whether improvements in binge-eating and vomiting were independent of depression status at baseline. | G1: Fluoxetine 60 mg-Hi depressed-8-wk trial | NR | Males and Females who met DSM-IIIR criteria for BN; at least 3 vomiting episodes per week after binge eating for at least six months; age 18 and older. | Subjects were seen by a physician and/or study coordinator weekly during the initial placebo lead-in phase, were seen every other week for the first four wks of the double-blind phase, and then monthly. Subjects completed a bulimic activity diary (i.e. recording the number of weekly vomiting and binge-eating episodes) and were administered a HRSD, EDI, and Patient's Global Impression (PGI) scales at each visit. Clinicians subjectively rated the subject's global improvement during each visit. | Analyses included ANOVAs to assess sig between group diffs in change of median frequencies of binge eating and vomiting from baseline to endpoint. | Poor | | Binge-eating (median % improvement):
Companion article: | | G2: Fluoxetine 20 mg-Hi depressed-8-wk trial | Sex: | Exclusion: | Tx responders were defined as those who met the criteria of at least 50% improvement in binge-eating and vomiting frequency. | | Intent to treat: | | G1: ~75% (P = NR)
Goldstein et al., 1995 and Fluoxetine BN Collaborative Study Group, 1992 | | G3: Placebo-Hi depressed-8-wk trial (N = 61) | NR | Previous participation in a fluoxetine study; had taken fluoxetine within 5 wks before enrollment or had a cumulative lifetime fluoxetine dose of more than 140 mg; pregnant or lactating; a medically unstable condition; psychosis; acute suicidal ideation; a history of seizures; a diagnosis of AN; a diagnosis of organic brain disease; an allergy to fluoxetine or a history of severe allergies or multiple adverse drug reactions; hypertension treated with guanethidine, reserpine, clinidine, or methyldopa; having used MAOI's within two wks of enrollment or who anticipated using an MAOI within 5 wks of study completion; use of lithium, tryptophan or any other psychoactive agent in the wk prior to enrollment; had initiated some other form of treatment for BN within 1 month prior to enrollment; 2 wk placebo responders (i.e. 75% reduction in the number of vomiting episodes or had < 3 vomiting episodes per wk). | | | Yes | | G2: ~28% (P = NS)
Setting: | | G4: Fluoxetine 60mg-Lo depressed-8-wk trial | Race/ethnicity: | | | | Blinding: | | G3: ~40% (P = NR)
15 outpatient psychiatry clinics in the US (See Goldstein, Wilson, Thompson et al., 1995) | | G5: Fluoxetine 20 mg-Lo depressed-8-wk trial | NR | | | | Double | | G4: ~61% (P = NR)
Enrollment period: | | G6: Placebo-Lo depressed-8-wk trial (N = 66) | | | | | Adverse events: | | G5: ~48% (P = NS)
NR | | G7: Fluoxetine 60 mg-Hi depressed 16-wk trial | | | | | NR | | G6: ~19% (P = NR)
See Goldstein et al., 1995 for specific details from original RCTs. Data from Fluoxetine Bulimia Nervosa Collaboration Study Group, 1992 unknown. | | G8: Placebo-Hi depressed-16-wk trial (N = 39) | | | | | Funding: | | Diff between groups in change over time
| | G9: Fluoxetine 60 mg-Lo depressed-16-wk trial | | | | | Eli Lilly | | G1 > G3 (P = 0.03)
| | G10: Placebo-Lo depressed-16-wk trial (N = 61) | | | | | | | G1 > G2 (P = 0.00)
| | G11: Fluoxetine 60 mg-depressed-8-wk trial | | | | | | | G4 > G6 (P = 0.02)
| | G12: Fluoxetine 20 mg-depressed-8-wk trial | | | | | | | G4 = G5 (P = NS)
| | G13: Placebo-depressed-8-wk trial (N = 47) | | | | | | | Vomiting (median % improvement):
| | G14: Fluoxetine 60 mg-nondepressed-8 wk trial | | | | | | | G1: ~65% (P = NR)
| | G15: Fluoxetine 20 mg-nondepressed-8 wk trial | | | | | | | G2: ~21% (P = NS)
| | G16: Placebo-nondepressed-8-wk trial (N = 73) | | | | | | | G3: ~15% (P = NR)
| | G17: Fluoxetine 60 mg-depressed-16-wk trial | | | | | | | G4: ~48% (P = NR)
| | G18: Placebo-depressed-16-wk trial (N = 22) | | | | | | | G5: ~50% (P = 0.014)
| | G19: Fluoxetine 60 mg-nondepressed-16-wk trial | | | | | | | G6: ~13% (P = NR)
| | G20: Placebo-nondepressed-16-wk trial (N = 73) | | | | | | | Diff between groups in change over time
| | Enrollment: | | | | | | | G1 > G2 (P = 0.01)
| | Participants were male and female outpatients at each of the 15 centers. Details regarding the recruiting methods were not reported | | | | | | | G1 > G3 (P = 0.002)
| | | | | | | | | G4 = G5 (P = NS)
| | | | | | | | | G4 > G6 (P = 0.003)
| | | | | | | | | For 16-wk trial stratified by median HRSD:
| | | | | | | | | Binge-eating (median % improvement):
| | | | | | | | | G7: ~42% (P = NR)
| | | | | | | | | G8: ~12% (P = NR)
| | | | | | | | | G9: ~50% (P = NR)
| | | | | | | | | G10: ~22% (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G7 > G8 (P = 0.042)
| | | | | | | | | G9 > G10 (P = 0.002)
| | | | | | | | | Vomiting (median % improvement):
| | | | | | | | | G7: ~50% (P = NR)
| | | | | | | | | G8: ~18% (P = NR)
| | | | | | | | | G9: ~51% (P = NR)
| | | | | | | | | G10: ~30% (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G7 > G8 (P = 0.03)
| | | | | | | | | G9 > G10 (P = 0.002)
| | | | | | | | | For 8-wk trial stratified by current or hx of depression:
| | | | | | | | | Binge-eating (median % improvement):
| | | | | | | | | G11: ~71% (P = NR)
| | | | | | | | | G12: ~30% (P = NR)
| | | | | | | | | G13: ~38% (P = NR)
| | | | | | | | | G14: ~67% (P = NR)
| | | | | | | | | G15: ~53% (P = NR)
| | | | | | | | | G16: ~32% (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G11 > G13 (P = 0.04)
| | | | | | | | | G14 > G16 (P = 0.005)
| | | | | | | | | G12 = G13 (P = NS)
| | | | | | | | | G15 = G16 (P = NS)
| | | | | | | | | G11 > G12 (P = 0.02)
| | | | | | | | | G14 > G15 (P = 0.03)
| | | | | | | | | Vomiting (median % improvement):
| | | | | | | | | G11: ~63% (P = NR)
| | | | | | | | | G12: ~29% (P = NR)
| | | | | | | | | G13: ~15% (P = NR)
| | | | | | | | | G14: ~55% (P = NR)
| | | | | | | | | G15: ~31% (P = NR)
| | | | | | | | | G16: ~12% (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G11 > G13 (P = 0.005)
| | | | | | | | | G14 > G16 (P = 0.0004)
| | | | | | | | | G12 = G13 (P = NS)
| | | | | | | | | G15 = G16 (P = NS)
| | | | | | | | | G11 = G12 (P = NS)
| | | | | | | | | G14 > G15 (P = 0.04)
| | | | | | | | | For 16-wk trial stratified by current or hx of depression:
| | | | | | | | | Binge-eating (median % improvement):
| | | | | | | | | G17: ~48% (P = NR)
| | | | | | | | | G18: ~5% (P = NR)
| | | | | | | | | G19: ~50% (P = NR)
| | | | | | | | | G20: ~20% (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G17 > G18 (P = 0.005)
| | | | | | | | | G19 > G20 (P = 0.01)
| | | | | | | | | Vomiting (median % improvement):
| | | | | | | | | G17: ~53% (P = NR)
| | | | | | | | | G18: ~8% (P = NR)
| | | | | | | | | G19: ~50% (P = NR)
| | | | | | | | | G20: ~29% (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G17: > G18 (P = 0.001)
| | | | | | | | | G19: > G20 (P = 0.005)
Author, yr: | Research objective: | Groups: | Age, yrs, median (range): | Inclusion: | 1 wk drug-free pre-screen period followed by 2 wks of single-blind placebo run-in administration, followed by random assignment (1:3) to placebo or 60 mg of fluoxetine for 16 wks. | ANOVAs on rank transformed data for continuous efficacy and safety variables using Bonferroni correction for controlling Type I error; Pearson's X^2^ and Mantel-Haenszel X^2^ tests for linear associations in conjunction with computing confidence intervals for odds ratios for comparing among bulimic responder and non-responder groups; Pearson's X^2^ tests for subject dispositional and adverse event data. | Score: | Vomiting episodes/wk, median (range): | % Change in vomiting episodes/wk, median: | HRSD, median: | Change in HRSD, median (Range): | Wt, kg, median (range): | Change in wt, kg, median:
Goldstein et al., 1995 | As an extension of a previous 8-wk RCT (see Fluoxetine Bulimia Nervosa Collaborative Study Group, 1992), the primary aim was to assess the efficacy and safety of fluoxetine versus placebo in improving principal symptoms of BN (i.e., binge eating and purging behavior) during a 16-wk, double blind RCT. Secondary aims: evaluating improvements in self-reported depression, eating dysregulation and both patient and clinician-rated global psychiatric impressions. | G1: Fluoxetine (N = 296) | G1: 27 (17–63) | Met DSM III-R criteria for BN; 3 vomiting episodes per wk after binge eating for at least 6 mos; age 18 and older. | Subjects were seen by a physician and/or study coordinator wkly during initial placebo lead-in phase, seen every other wk for first four wks of double-blind phase, and then moly. Subjects completed bulimic activity diary (i.e., recording number of wkly vomiting and binge-eating episodes) and administered HRSD, EDI, and PGI scales at each visit. Clinicians subjectively rated subject's global improvement during each visit. | | Fair | G1: 9 (1–94) | G1, G2: data shown in figure | G1: 10 | G1: -4 (-20–20) (P = NR) | G1: 58 (39–132) | G1: -0.45 (P = NR)
Companion article: | | G2: Placebo (N = 102) | G2: 26 (17–61) | Exclusion: | Tx responders defined as those who met criteria of at least 50% improvement in binge-eating and vomiting frequency. | | Intent to treat: | G2: 9 (0–225) | Diff between groups (P < 0.017) | G2: 8.5 | G2: -3 (-27 - 9) (P = NR) | G2: 58 (43–96) | G2: 0.16 (P = NR)
Fluoxetine Bulimia Nervosa Collaborative Study Group, 1992 and Goldstein et al., 1999 | | Enrollment: | (P = NS) | Previous participation in a fluoxetine study; had taken fluoxetine within 5 wks before enrollment or had a cumulative lifetime fluoxetine dose of more than 140 mg; pregnant or lactating; medically unstable condition; psychosis; acute suicidal ideation; hx of seizures; dx of AN; a dx of organic brain disease; allergy to fluoxetine or hx of severe allergies or multiple adverse drug reactions; hypertension treated with guanethidine, reserpine, clinidine, or methyldopa; having used MAOI's within 2 wks of enrollment or who anticipated using an MAOI within 5 wks of study completion; use of lithium, tryptophan or any other psychoactive agent in the wk prior to enrollment; had initiated some other form of tx for BN within 1 mo prior to enrollment; 2 wk placebo responders (i.e., 75% reduction in the number of vomiting episodes or had < 3 vomiting episodes per wk). | | | Yes | (P = NS) | G1 better than G2 through wk 10, and during wk 13 and 16 | (P = NS) | Diff between groups (P = NS) | (P = NS) | Diff between groups (P = 0.001)
Setting: | | Male and female outpatients at 15 centers. Details regarding the recruiting methods not reported | Sex: | | | | Blinding: | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR) | | G1 better than G2
15 outpatient psychiatry clinics in the US | | - 483 enrolled; - 398 randomized at a ratio of 3:1 (fluoxetine: placebo); - 225 completers | % Female | | | | Double | | | | | | Diff between groups in change over time (P = NR)
Enrollment period: | | G1: 59.5% | G1: 95.3 | | | | Adverse events (% reporting): | Vomiting days/wk, median (range): | Change in vomiting episodes/wk at endpoint, median (range): | CGI, median (range): | CGI, median (range):
NR | | G2: 48% | G2: 99.0 | | | | Insomnia: | G1: 6 (0–15) | G1: -4 (-64 - 34) (P = NR) | G1: 5 (3–7) | G1: 2 (1–6) (P = NR)
| | (P = 0.045) | (P = NS) | | | | G1: 34.5 | G2: 5.5 (0–12) | G2: -2 (-55 - 58) (P = NR) | G2: 5 (3–7) | G2: 3 (1–6) (P = NR)
| | | Race/ethnicity: | | | | G2: 18.6 | (P = NS) | Diff between groups (P < 0.0005) | (P = NS) | Diff between groups (P < 0.0001)
| | | % White | | | | (P ≤ 0.05) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | G1: 96.6 | | | | Nausea: | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | G2: 97.1 | | | | G1: 30.4 | | % Change in vomiting episodes/wk at endpoint, median:
| | | (P = NS) | | | | G2: 12.7 | | G1: -50 (P = NR)
| | | Fasting days/wk median (range): | | | | (P ≤ 0.001) | | G2: -21 (P = NR)
| | | G1: 0 (0–7) | | | | Asthenia: | | Diff between groups (P < 0.0001)
| | | G2: 0 (0–7) | | | | G1: 21.3 | | G1 better than G2
| | | (P = NS) | | | | G2: 6.9 | | Diff between groups in change over time (P = NR)
| | | Diuretic abuse days/wk median (range): | | | | (P ≤ 0.001) | | Vomiting Remission:
| | | G1: 0 (0–14) | | | | Anxiety: | | G1: 19%
| | | G2: 0 (0–8) | | | | G1: 17.6 | | G2: 12%
| | | (P = NS) | | | | G2: 8.8 | | (P = NR)
| | | Laxative abuse days/wk median (range): | | | | (P ≤ 0.05) | | Vomiting Treatment Responders (≥ 50% improvement):
| | | G1: 0 (0–14) | | | | Tremor: | | G1: 53.1%
| | | G2: 0 (0–9) | | | | G1: 14.2 | | G2: 35.0%
| | | (P = NS) | | | | G2: 2.0 | | Diff between groups (P = 0.002)
| | | BN Behavior: | | | | (P ≤ 0.001) | | G1 better than G2
| | | Bingeing | | | | Dizziness: | Binge-eating episodes/wk, median (range) | Change in binge-eating episodes/wk, median: | PGI: | PGI, median (range):
| | | G1: 100 % | | | | G1: 12.5 | G1: 9 (0–68) | G1, G2: data shown in figure | G1: NR | G1: 2 (1–6) (P = NR)
| | | G2: 99.0% | | | | G2: 3.9 | G2: 9.5 (1–150) | Diff between groups (P < 0.01) | G2: NR | G2: 3 (1–5) (P = NR)
| | | (P = NS) | | | | (P ≤ 0.05) | (P = NS) | G1 better than G2 through wk 9, and during wk 13 and 16 | (P = NR) | Diff between groups (P < 0.0001)
| | | Vomiting | | | | Yawning: | | Diff between groups in change over time (P = NR) | | G1 better than G2
| | | G1: 99.0% | | | | G1: 12.2 | | Change in binge-eating episodes/wk at endpoint, median (range): | | Diff between groups in change over time (P = NR)
| | | G2: 100% | | | | G2: 0.0 | | G1: -4 (-59 - 30)
| | | (P = NS) | | | | (P ≤ 0.001) | | G2: -2 (-143 - 40)
| | | Laxative use | | | | Sweating: | | Diff between groups (P < 0.0003)
| | | G1: 11.8% | | | | G1: 9.5 | | G1 better than G2
| | | G2: 16.6% | | | | G2: 2.0 | | Diff between groups in change over time (P = NR)
| | | (P = NS) | | | | (P ≤ 0.05) | Binge-eating days/wk, median (range): | % Change in binge-eating episodes/wk at endpoint, median:
| | | Diuretic use | | | | Decreased Libido: | G1: 6 (0–15) | G1: -50 (P = NR)
| | | G1: 6.9% | | | | G1: 6.4 | G2: 6 (1–12) | G2: -18 (P = NR)
| | | G2: 7.4% | | | | G2: 1.0 | (P = NS) | Diff between groups (P < 0.0002)
| | | (P = NS) | | | | (P ≤ 0.05) | | G1 better than G2
| | | Fasting | | | | Depression: | | Diff between groups in change over time (P = NR)
| | | G1: 14.7% | | | | G1: 10.1 | | Binge-eating Remission (%):
| | | G2: 17.9% | | | | G2: 18.6 | | G1: 18.3%
| | | (P = NS) | | | | (P ≤ 0.05) | | G2: 12.0%
| | | > 1 Purging Behavior: | | | | Myalgia: | | Diff between groups (P = NR)
| | | G1: 27.5% | | | | G1: 4.7 | | Binge-eating Treatment Responder (≥ 50% improvement):
| | | G2: 32.8% | | | | G2: 11.8 | | G1: 51.4%
| | | (P = NS) | | | | (P ≤ 0.05) | | G2: 36.0%
| | | | | | | Emotional lability: | | Diff between groups (P = 0.008)
| | | | | | | G1: 2.7 | | G1 better than G2)
| | | | | | | G2: 7.8 | EDI Total: | Change in EDI Total, median:
| | | | | | | (P ≤ 0.05) | G1: NR | Total:
| | | | | | | Conjunctivitis: | G2: NR | G1: -21 (P = NR)
| | | | | | | G1: 0.3 | | G2: -12 (P = NR)
| | | | | | | G2: 2.9 | | Diff between groups (P = 0.006)
| | | | | | | (P ≤ 0.05) | | G1 better than G2
| | | | | | | Funding: | | Diff between groups in change over time (P = NR)
| | | | | | | Eli Lilly | EDI Bulimia: | Change in EDI Bulimia, median:
| | | | | | | | G1: NR | G1: -6 (P = NR)
| | | | | | | | G2: NR | G2: -3 (P = NR)
| | | | | | | | | Diff between groups (P = 0.003)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDI Drive for Thinness: | Change in EDI Drive for Thinness, median:
| | | | | | | | G1: NR | G1: -3 (P = NR)
| | | | | | | | G2: NR | G2: -1 (P = NR)
| | | | | | | | | Diff between groups (P = 0.040)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDI Body Dissatisfaction: | Change in EDI Body Dissatisfaction, median:
| | | | | | | | G1: NR | G1: NR (P = NR)
| | | | | | | | G2:NR | G2: NR (P = NR)
| | | | | | | | | Diff between groups(P= NS)
| | | | | | | | | Diff between groups in change over time(P= NR)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | 2 to 4 wk screening and washout period during which baseline values established. | % change from baseline compared by a Wilcoxon rank sum test; ANCOVA; Cochran-Mantel-Haenszel test stratified by site | Score: | EDI: Bulimia/uncontrollable overeating, mean (SD): | EDI: Bulimia/uncontrollable overeating, mean (SD): | | Change in HAM- A, mean:
Hedges et al., 2003 | To investigate topiramete's effect on psychological symptoms associated with disordered eating. | G1: Topiramate (N = 34) | G1: 29.0 (9.7) | Age: 16–50; DSM IV criteria for BN for at least 6 mo. | Study med: 25 mg or 100 mg tablets of topiramate or placebo. Topiramate started at 25 mg/day for the first wk and titrated by 25 to 50 mg/wk until max tolerated dose, complete or near-complete efficacy, or max daily dose of 400 mg achieved. Once this level was achieved, patients continued at that dose through wk 10. Patients allowed 1 reduction in dose during titration period if they experienced side effects. | | Fair | G1: 10.4 (5.0) | G1: 5.9 (5.5) | | G1: -4.0
Companion article: | | G2: Placebo (N = 34) | G2: 29.6 (8.1) | Exclusion: | Patients seen wkly for 10 wks and then tapered from study meds and offered option to continue into a 40 wk open label extension. | | Intent to treat: | G2: 11.5 (5.1) | G2: 10.3 (6.8) | | G2: -1.7
Hoopes et al., 2003 | | Enrollment: | (P = NS) | Recent hx of clinically sig suicidality, substance abuse, bipolar I or II, major depressive, anxiety, or personality disorder that could have interfered with assessments. Hx of nephrolithiasis. Currently pregnant or lactating. Use of psychoactive meds within 2 wks prior to the study other than occasional use of short-acting sedatives for sleep. Dx of AN, BMI of ≤ 17, serum potassioum level < 3.0 mmol/L. Patients were not permitted to initiate psychotherapy during the study, but were allowed to be randomized if psychotherapy had been started 3 mo prior to the study. | Topiramate dose, mean (range): 100 mg/day (25–400 mg/day). | | Yes | (P = NS) | Diff between groups (P = NR) | | Diff between groups (P = NR)
Setting: | | - Randomized (N = 69); - Discontinued after washout:; - Total Sample (N = 1); - G1 (N = 1); - G2 (N = 0); - Evaluable for safety and received at least 1 dose of study med:; - Total (N = 68); - G1 (N = 34); - G2 (N = 34); - Returned for at least 1 post-baseline assessment (included in ITT):; - Total (N = 64); - G1 (N = 31); - G2 (N = 33); - Discontinued tx:; 1. Total (N = 28); 2. G1 (N = 12); 3. G2 (N = 16); - Completed:; 1. Total (N = 40); 2. G1 (N = 22); 3. G2 (N = 18); 4. (P = NR) | Sex: | | | | Blinding: | | Diff between groups in change over time (P = 0.005) | | Diff between groups in change over time (P = 0.046)
Idaho and UT Outpatient | | | Female, N: | | | | Double | | G1 better than G2 | | G1 better than G2
Enrollment period: | | | G1: 33 | | | | Adverse events, N (%): | EDI: Body dissatisfaction: mean (SD): | EDI: Body dissatisfaction: mean (SD): | | Change in HAM- D, mean:
4/1999 to 12/2000 | | | G2: 34 | | | | Fatigue: | G1: 16.7 (8.2) | G1: 14.2 (8.5) | | G1: -2.9
| | | (P = NS) | | | | G1: 11 (32%) | G2: 19.1 (8.7) | G2: 19.9 (8.5) | | G2: -1.3
| | | Race/ethnicity: | | | | G2: 8 (24%) | (P = NS) | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | NR | | | | Flulike symptoms: | | Diff between groups in change over time (P = 0.007) | | Diff between groups in change over time (P = NS)
| | | Wt, kg (mean): | | | | G1: 10 (29%) | | G1 better than G2
| | | G1: 61.5 | | | | G2: 6 (18%) | EDI: Drive for thinness, mean (SD): | EDI: Drive for thinness, mean (SD): | | PGI, % improved:
| | | G2: 67.4 | | | | Paresthesia: | G1: 14.1 (5.6) | G1: 10.9 (5.7) | | G1: 61.3%
| | | (P = NR) | | | | G1: 8 (24%) | G2: 16.2 (4.0) | G2: 15.3 (4.4) | | G2: 36.4%
| | | | | | | G2: 2 (6%) | (P = NS) | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | | | | | Hypoesthesia: | | Diff between groups in change over time (P = 0.002) | | Diff between groups in change over time(P = 0.004)
| | | | | | | G1: 7 (21%) | | G1 better than G2 | | G1 better than G2
| | | | | | | G2: 1 (3%) | EAT: Bulimia/food preoccupation, mean (SD): | EAT: Bulimia/food preoccupation, mean (SD): | | Change in PGI, %, mean:
| | | | | | | Nausea: | G1: 11.5 (4.3) | G1: 7.9 (5.2) | | G1:
| | | | | | | G1: 6 (18%) | G2: 12.4 (3.9) | G2: 10.9 (5.2) | | No change: 38.7%
| | | | | | | G2: 3 (9%) | (P = NS) | Diff between groups (P = NR) | | Minimally improved: 25.8%
| | | | | | | Constipation: | | Diff between groups in change over time (P = 0.19) | | Much improved: 22.6%
| | | | | | | G1: 5 (15%) | | G1 better than G2 | | Very much improved: 12.9%
| | | | | | | G2: 2 (6%) | EAT: Dieting, mean (SD): | EAT: Dieting, mean (SD): | | G2:
| | | | | | | Difficulty with Concentration: | G1: 18.3 (8.3) | G1: 15.2 (9.0) | | No change: 63.6%
| | | | | | | G1: 5 (15%) | G2: 22.5 (7.5) | G2: 20.6 (8.1) | | Minimally improved: 30.3%
| | | | | | | G2: 2 (6%) | (P = NS) | Diff between groups (P = NR) | | Much improved: 6.1%
| | | | | | | Nervousness: | | Diff between groups in change over time (P = 0.031) | | Very much improved: 0%
| | | | | | | G1: 4 (12%) | | G1 better than G2
| | | | | | | G2: 2 (6%) | EAT: Oral control, mean (SD): | EAT: Oral control, mean (SD):
| | | | | | | Headache: | G1: 2.8 (3.4) | G1: 2.5 (3.1)
| | | | | | | G1: 4 (12%) | G2: 3.3 (3.5) | G2: 2.8 (3.4)
| | | | | | | G2: 5 (15%) | (P = NS) | Diff between groups (P = NR)
| | | | | | | Diff between groups in all adverse effects (P = NR) | | Diff between groups in change over time (P = NS)
| | | | | | | Funding: | EAT: Total score, mean (SD): | EAT: Total score, mean (SD):
| | | | | | | Ortho-McNeil Pharmaceutical, Inc. | G1: 32.5 (12.8) | G1: 25.6 (14.6)
| | | | | | | | G2: 37.8 (12.0) | G2: 33.8 (13.6)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.022)
| | | | | | | | | G1 better than G2
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Participants underwent 2 to 4 wk screening and washout period during which baseline values established. | Wilcoxon rank sum test, ANCOVA, Cochran-Mantel-Haenszel test stratified by site | Score: | Binge and/or Purge days per wk, mean (SD): | Change in binge/purge days per wk, %, mean: | CGI-S, mean (SD): | CGI-S, mean (SD): | Wt, kg, mean (SD): | Change in wt, kg (lb), mean:
Hoopes et al., 2003 | To assess the efficacy and safety of topiramate in BN | G1: Topiramate (N = 34) | G1: 29.0 (9.7) | Age: 16–50; DSM IV criter for BN for at least 6 mo. | Study med provided as 25 mg or 100 mg tablets of topiramate or placebo. Topiramate started at 25 mg/day for first wk and was then titrated by 25 to 50 mg/wk until max tolerated dose, complete or near-complete efficacy, or max daily dose of 400 mg achieved. Once this level was achieved, patients continued at that dose through wk 10. Patients allowed 1 reduction in dose during the titration period if they experienced side effects. | | Fair | G1: 5.0 (1.6) | G1: -44.8% | G1: 4.9 (0.7) | G1: 3.7 (1.4) | G1: 61.3 (10.3) | G1: -1.8 (-4.0)
Companion article: | | G2: Placebo (N = 34) | G2: 29.6 (8.1) | Exclusion: | Patients seen wkly for 10 wks and then tapered from study meds and offered the option to continue into a 40 wk open label extension. | | Intent to treat: | G2: 5.1 (1.5) | G2: -10.7% | G2: 4.6 (0.7) | G2: 4.3 (1.1) | G2: 65.9 (14.2) | G2: 0.2 (0.4)
Hedges et al., 2003 | | Enrollment: | (P = NS) | Recent hx of clinically sig suicidality, substance abuse, bipolar I or II, major depressive, anxiety, or personality disorder that could interfere with assessments. Hx of nephrolithiasis. Currently pregnant or lactating. Use of psychoactive meds within 2 wks prior to the study other than occasional use of short-acting sedatives for sleep. Dx of AN, BMI of ≤ 17, serum potassioum level < 3.0 mmol/L. Patients not permitted to initiate psychotherapy during the study, but allowed to be randomized if psychotherapy had been started 3 mo prior to study. | Topiramate dose, mean (range): 100 mg/day (25–400 mg/day). | | Yes | (P = NS) | Diff between groups (P = 0.004) | (P = NS) | Diff between groups (P = 0.022) | (P = NS) | Diff between groups (P = 0.004)
Setting: | | - Randomized (N = 69); - Discontinued after washout:; - Total (N = 1); - G1 (N = 1); - G2 (N = 0); - Evaluable for safety and received at least 1 dose of study med:; - Total (N = 68); - G1 (N = 34); - G2 (N = 34); - Returned for at least 1 post-baseline assessment (included in ITT):; - Total (N = 64); - G1 (N = 31); - G2 (N = 33); - Discontinued tx:; - Total (N = 28); - G1 (N = 12); - G2 (N = 16); - Completed:; - Total (N = 40); - G1 (N = 22); - G2 (N = 18) | Sex: | | | | Blinding: | | G1 better than G2) | | G1 better than G2 | | G1 better than G2)
Idaho and UT | | | Female, N: | | | | Double | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
Outpatient, USA | | | G1: 33 | | | | Adverse events: | | Achieved at least moderate improvement (≥ 50% reduction) in number of binge and/or purge days, N (%):
Enrollment period: | | | G2: 34 | | | | G1: 1 drop out due to nausea | | G1: 16/31 (51.6%)
4/1999 to 12/2000 | | | (P = NS) | | | | G2: 2 drop outs due to facial rash and irritability. | | G2: 8/33 (24.2%)
| | | Race/ethnicity: | | | | No serious adverse events, generally mild/moderate in nature, resolved with time or dose reduction. | | Diff between groups (P = 0.012)
| | | NR | | | | N (%): | | G1 better than G2
| | | Reported Self-induced vomiting, N (%): | | | | Fatigue: | | Diff between groups in change over time (P = NR)
| | | 64 (100) | | | | G1: 11 (32) | | Achieved marked improvement (≥ 75% reduction) or complete remission of binge and/or purge days, N (%):
| | | (P = NS) | | | | G2: 8 (24) | | G1: 9/31 (29.0%)
| | | Reported Laxative use, N (%): | | | | Influenza-like symptoms: | | G2: 2/33 (6.1%)
| | | 13 (20.3%) | | | | G1: 10 (29) | | Diff between groups (P = 0.021)
| | | (P = NS) | | | | G2: 6 (18) | | G1 better than G2
| | | Reported diuretic use, N (%): | | | | Paresthesia: | | Diff between groups in change over time (P = NR)
| | | 5 (7.8%) | | | | G1: 8 (24) | | Remission of binge and/or purge days, N (%):
| | | (P = NS) | | | | G2: 2 (6) | | G1: 7/31 (22.6%)
| | | Reported fasting, N (%): | | | | Hypoesthesia: | | G2: 2/33 (6.1%)
| | | 11 (17.2%) | | | | G1: 7 (21) | | Diff between groups (P = NS)
| | | (P = NS) | | | | G2: 1 (3) | | Diff between groups in change over time (P = NR)
| | | | | | | Nausea: | Binge days per wk, mean (SD): | Change in binge days per wk, %, mean: | CGI-I, mean (SD): | CGI-I, mean (SD):
| | | | | | | G1: 6 (18) | G1: 4.8 (1.7) | G1: -48.2% | G1: NR | G1: 2.8 (1.3)
| | | | | | | G2: 3 (9) | G2: 4.7 (1.7) | G2: -17.7% | G2: NR | G2: 3.6 (1.0)
| | | | | | | Constipation: | (P = NS) | Diff between groups (P = 0.015) | | Diff between groups (P = 0.004)
| | | | | | | G1: 5 (15) | Binge episodes per wk, mean (SD): | G1 better than G2) | | G1 better than G2
| | | | | | | G2: 2 (6) | G1: 10.8 (10.4) | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | Difficulty with concentration/ attention: | G2: 11.3 (10.7) | Achieved at least moderate improvement in number of binge days, N (%):
| | | | | | | G1: 5 (15) | (P = NS) | G1: 19/31 (61.3%)
| | | | | | | G2: 2 (6) | | G2: 10/33 (30.3%)
| | | | | | | Headache: | | Diff between groups (P = 0.032)
| | | | | | | G1: 4 (12) | | G1 better than G2
| | | | | | | G2: 5 (15) | | Diff between groups in change over time (P = NR)
| | | | | | | Nervousness: | | Change in wkly binge frequency, %, mean:
| | | | | | | G1: 4 (12) | | G1: -49.2%
| | | | | | | G2: 2 (6) | | G2: -28.0%
| | | | | | | (P = NR) | | Diff between groups (P = NS)
| | | | | | | Funding: | | Diff between groups in change over time (P = NRS)
| | | | | | | Ortho-McNeil Pharmaceutical, Inc. | Purge days per wk, mean (SD): | Change in purge days per wk, %, mean:
| | | | | | | | G1: 4.8 (1.9) | G1: -43.4%
| | | | | | | | G2: 4.8 (1.6) | G2: -16.6%
| | | | | | | | (P = NS) | Diff between groups (P = 0.016)
| | | | | | | | Purge episodes per wk, mean (SD): | G1 better than G2
| | | | | | | | G1: 13.3 (13.5) | Diff between groups in change over time (P = NR)
| | | | | | | | G2: 12.4 (13.0) | Achieved at least moderate improvement in number of purge days per wk, N (%):
| | | | | | | | (P = NS) | G1: 16/31 (51.5%)
| | | | | | | | | G2: 8/33 (24.2%)
| | | | | | | | | Diff between groups (P = 0.021)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Change in wkly purge frequency, %, mean:
| | | | | | | | | G1: -49.8%
| | | | | | | | | G2: -21.6%
| | | | | | | | | Diff between groups (P = 0.016)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Bulimic Intensity Scale Score, mean (SD): | Change in Bulimic Intensity Scale Score, %, mean:
| | | | | | | | G1: 7.1 (1.6) | G1: -37%
| | | | | | | | G2: 7.4 (1.8) | G2:14%
| | | | | | | | (P = NS) | Diff between groups (P = 0.007)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Carbohydrate Craving Scale score, mean (SD): | Change in Carbohydrate Craving Scale score, %:
| | | | | | | | G1: 7.0 (2.6) | G1: -43%
| | | | | | | | G2: 7.3 (2.4) | G2: -16%
| | | | | | | | (P = NS) | Diff between groups (P = 0.011)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, yrs, mean: | Inclusion: | All subjects went through single-blind placebo run-in phase for first wk of study. Subjects then randomized to either 60 mg of fluoxetine or placebo for 8 wks. | Mann-Whitney U test to assess between group diffs on continuous variables of interest and Fisher's exact test to evaluate between group diffs on the categorical variables being studied at baseline, 4 wks and at 8 wks of tx. Repeated measures ANOVA for diffs between groups at mid-tx (4 wks) and post-tx (8 wks) | Score: | Binges/wk, mean (SD): | End of Treatment (8 wks): | HDRS-21, mean (SD): | At mid-tx (4 wks): | Wt, kg, mean (SD): | End of Treatment (8 wks):
Kanerva, Rissanen, and Sarna, 1995 | To assess the efficacy and safety of fluoxetine (an SSRI) versus placebo in the tx of BN and its effect on associated eating-related attitudes, depression, and anxiety symptoms. | G1: fluoxetine (N = 24) | Total Sample: 25.2 | Female; met DSM III-R criteria for BN; age 15+; BMI; ≥16 | | | Fair | G1: 9.2 (NR) | Binges/wk, mean (SD): | G1: 12.2 (4.6) | HDRS-21, mean (SD): | G1: 62.2 (15.4) | Wt, kg, mean (SD):
Setting: | | G2: placebo (N = 26) | Sex: | Exclusion: | | | Intent to treat: | G2: 10.5 (NR) | G1: 5.3 (P= NR) | G2: 11.7 (5.8) | G1: 7.4 (4.7) (P= NR) | G2: 63.0 (17.0) | G1: 61.2 (12.9) (P= NR)
Single center; outpatient; location: Department of Psychiatry and Adolescent Psychiatry of Helsinki University Central Hospital; Helsinki, Finland | | Enrollment: | Female: 100% | Pregnancy; lactation; inadequate contraception; major somatic or psychiatric illness (e.g., recent drug or alcohol abuse, severe depression or suicidal features, recent or concurrent use of other psychotropic drugs such as lithium or MAOIs); previous tx with fluoxetine; concurrent psychiatric tx | | | No | (P= NR) | G2: 5.7 (P= NR) | (P= NR) | G2: 10.9 (5.6) (P= NR) | (P= NR) | G2: 65.7 (16.1) (P= NR)
Enrollment period: | | - Potential subjects recruited through letters sent out to somatic and mental healthcare departments of hospital; - 50 enrolled; - 46 completers (G1: 22; G2: 24; P= NR) | Race/ethnicity: | | | | Blinding: | | Diff between groups (P= NR) | | Diff between groups (P= NR) | | Diff between groups (P= NR)
NR | | | NR | | | | Double | | Diff between groups in change over time (P= NS) | | Diff between groups in change over time (P= 0.0062) | | Diff between groups in change over time (P= 0.023)
| | | | | | | Adverse events: | | | | G1 better than G2 | | G1 better than G2
| | | | | | | Heart palpitations (G2: N = 1) | | | | End of Treatment (8 wks):
| | | | | | | Worsening hand tremor (G1: N = 5) | | | | HDRS-21, mean (SD):
| | | | | | | Funding: | | | | G1: 7.1 (5.1) (P= NR)
| | | | | | | Eli Lilly and Company grant | | | | G2: 9.5 (5.5) (P= NR)
| | | | | | | Helsinki University Central Hospital | | | | Diff between groups (P= NR)
| | | | | | | | | | | Diff between groups in change over time (P= 0.05)
| | | | | | | | | | | G1 better than G2
| | | | | | | | | Abstinence/Remission: | HDRS-17, mean (SD): | At mid-tx (4 wks):
| | | | | | | | | NR | G1: 9.3 (4.5) | HDRS-17, mean (SD):
| | | | | | | | | | G2: 9.4 (4.9) | G1: 5.9 (4.2) (P= NR)
| | | | | | | | | | (P= NR) | G2: 8.9 (4.6) (P= NR)
| | | | | | | | | | | Within groupchange from baseline (P= NR)
| | | | | | | | | | | Diff between groups (P= NR)
| | | | | | | | | | | Diff between groups in change over time (P= 0.030)
| | | | | | | | | | | G1 better than G2
| | | | | | | | | | | End of Treatment (8 wks):
| | | | | | | | | | | HDRS-17, mean (SD):
| | | | | | | | | | | G1: 5.5 (4.3) (P= NR)
| | | | | | | | | | | G2: 7.7 (4.8) (P= NR)
| | | | | | | | | | | Diff between groups (P= NR)
| | | | | | | | | | | Diff between groups in change over time (P= NS)
| | | | | | | | BITE, mean (SD): | BITE, mean (SD): | HDRS-Depression mean (SD): | At mid-tx (4 wks):
| | | | | | | | G1: 24.3 (2.3) | G1: 22.3 (4.3) (P= NR) | G1: 5.3 (2.6) | HDRS-Depression, mean (SD):
| | | | | | | | G2: 23.9 (3.5) | G2: 22.1 (5.4) (P= NR) | G2: 5.1 (2.4) | G1: 2.2 (1.9) (P= NR)
| | | | | | | | (P= NR) | Diff between groups (P= NR) | (P= NR) | G2: 4.9 (2.8) (P= NR)
| | | | | | | | | Diff between groups in change over time (P= NS) | | Diff between groups (P= NR)
| | | | | | | | | | | Diff between groups in change over time (P= 0.0002)
| | | | | | | | | | | G1 better than G2
| | | | | | | | | | | End of Treatment (8 wks):
| | | | | | | | | | | HDRS-Depression, mean (SD):
| | | | | | | | | | | G1: 2.0 (2.0) (P= NR)
| | | | | | | | | | | G2: 4.2 (2.8) (P= NR)
| | | | | | | | | | | Diff between groups (P= NR)
| | | | | | | | | | | Diff between groups in change over time (P= 0.0003)
| | | | | | | | | | | G1 better than G2
| | | | | | | | EAT Dieting mean (SD): | EAT Dieting, mean (SD):
| | | | | | | | G1: 14.6 (7.2) | G1: 11.9 (7.0) (P= NR)
| | | | | | | | G2: 16.2 (7.6) | G2: 14.1 (7.6) (P= NR)
| | | | | | | | (P= NR) | Diff between groups (P= NR)
| | | | | | | | | Diff between groups in change over time (P= NS)
| | | | | | | | EAT Bulimia and Food Preoccupation, mean (SD): | EAT Bulimia and Food Preoccupation, mean (SD):
| | | | | | | | G1: 10.5 (4.0) | G1: 6.3 (4.0) (P= NR)
| | | | | | | | G2: 10.5 (4.1) | G2: 8.2 (4.5) (P= NR)
| | | | | | | | (P= NR) | Diff between groups (P= NR)
| | | | | | | | | Diff between groups in change over time (P= 0.033)
| | | | | | | | | G1 better than G2
| | | | | | | | EAT Oral Control, mean (SD): | EAT Oral Control, mean (SD):
| | | | | | | | G1: 3.4 (2.8) | G1: 2.9 (2.2) (P= NR)
| | | | | | | | G2: 3.6 (3.1) | G2: 3.0 (2.6) (P= NR)
| | | | | | | | (P= NR) | Diff between groups (P= NR)
| | | | | | | | | Diff between groups in change over time (P= NS)
| | | | | | | | EAT Total Score, mean (SD): | EAT Total Score, mean (SD):
| | | | | | | | G1: 40.3 (15.6) | G1: 29.6 (13.3) (P= NR)
| | | | | | | | G2: 42.5 (16.4) | G2: 35.9 (16.6) (P= NR)
| | | | | | | | (P= NR) | Diff between groups (P= NR)
| | | | | | | | | Diff between groups in change over time (P= NS)
| | | | | | | | EDI Drive for Thinness, mean (SD): | EDI Drive for Thinness, mean (SD):
| | | | | | | | G1: 10.7 (5.2) | G1: 9.2 (5.3) (P= NR)
| | | | | | | | G2: 13.6 (4.8) | G2: 11.6 (5.5) (P= NR)
| | | | | | | | (P= NR) | Diff between groups (P= NR)
| | | | | | | | | Diff between groups in change over time (P= NS)
| | | | | | | | EDI Bulimia, mean (SD): | EDI Bulimia, mean (SD):
| | | | | | | | G1: 11.4 (2.6) | G1: 6.7 (4.8) (P= NR)
| | | | | | | | G2: 12.9 (4.3) | G2: 7.4 (4.6) (P= NR)
| | | | | | | | (P= NR) | Diff between groups (P= NR)
| | | | | | | | | Diff between groups in change over time (P= NS)
| | | | | | | | EDI Body Dissatisfaction, mean (SD): | EDI Body Dissatisfaction mean (SD): | HDRS-Anxiety mean (SD): | At mid-tx (4 wks):
| | | | | | | | G1: 12.8 (9.9) | G1: 10.3 (9.4) (P= NR) | G1: 2.3 (1.1) | HDRS-Anxiety, mean (SD):
| | | | | | | | G2: 16.4 (7.9) | G2: 14.6 (8.1) (P= NR) | G2: 1.8 (1.0) | G1: 1.1 (1.0) (P= 0.0004)
| | | | | | | | (P= NR) | Diff between groups (P= NR) | (P= NR) | G2: 2.0 (1.4) (P= NR)
| | | | | | | | | Diff between groups in change over time (P= NS) | | Diff between groups (P= NR)
| | | | | | | | | | | Diff between groups in change over time (P= NR)
| | | | | | | | | | | End of Treatment (8 wks):
| | | | | | | | | | | HDRS-Anxiety, mean (SD):
| | | | | | | | | | | G1: 1.2 (1.2) (P= NR)
| | | | | | | | | | | G2: 1.8 (1.2) (P= NR)
| | | | | | | | | | | Diff between groups (P= NR)
| | | | | | | | | | | Diff between groups in change over time (P= 0.0013)
| | | | | | | | | | | G1 better than G2
| | | | | | | | EDI Total Score, mean (SD): | EDI Total Score, mean (SD): | Spielberger State Anxiety mean (SD): | At mid-tx (4 wks):
| | | | | | | | G1: 69.4 (22.5) | G1: 50.0 (23.7) (P= NR) | G1: 50.3 (11.8) | Spielberger State Anxiety, mean (SD):
| | | | | | | | G2: 80.5 (26.1) | G2: 61.9 (22.8) (P= NR) | G2: 45.8 (11.4) | G1: 39.8 (8.3) (P= 0.0004)
| | | | | | | | (P= NR) | Diff between groups (P= NR) | (P= NR) | G2: 48.2 (10.7) (P= NR)
| | | | | | | | | Diff between groups in change over time (P= NS) | | Diff between groups (P= NR)
| | | | | | | | | | | Diff between groups in change over time (P= NR)
| | | | | | | | | | | End of Treatment (8 wks):
| | | | | | | | | | | Spielberger State Anxiety, mean (SD):
| | | | | | | | | | | G1: 42.5 (8.3) (P= NR)
| | | | | | | | | | | G2: 44.5 (11.2) (P= NR)
| | | | | | | | | | | Diff between groups (P= NR)
| | | | | | | | | | | Diff between groups in change over time (P= 0.0004)
| | | | | | | | | | | G1 better than G2
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Both groups received identical looking capsules. Dosing started at 25 mg and increased on days 4, 7, 11, 15 and 19 to reach max permitted dose of 200 mg [mean = 175 mg, range 75 to 200 mg] given in a twice daily regimen. Clinicians could omit dose increment due to reported side effects. | Repeated measures ANCOVA for binge, purge and meal completion data. Binge and purge data log transformed prior to analysis. Only completers included in analyses. Baseline values included as covariates for eating and psychological measures. | Score: | Binge eating episodes/wk, mean (SD): | Binge eating episodes/wk, mean (SD): | HAM-D, mean (SD): | HAM-D, mean (SD): | Wt, kg, mean (SD): | Wt, kg, mean (SD):
Kennedy et al., 1993 | Evaluate efficacy of Brofaromine on eating behavior and attitude towards wt shape and psychopathology in women with BN. | G1: Brofaromine (N = 19) | G1: 27.6 (6.7) | Women, 18–40 yrs, met DSM III-R criteria for BN who engaged in vomiting as the primary method of purging. | After randomization, participants assessed once every 2 wks for remainder of the 8-wk trial. Sessions lasted 10 to 20 m and included review of symptom changes, adverse events, and compliance. | | Fair | G1: 9.1 (5.7) | G1: 3.5 (3.0) (P =NR) | G1: 14.5 (8.7) | G1: 7.5 (6.7) (P =NR) | G1: 70.2 (18.6) | G1: NR
Setting: | | G2: Placebo (N = 17) | G2: 25.9 (6.4) | Exclusion: | | | Intent to treat: | G2: 8.8 (3.7) | G2: 4.4 (3.9) (P =NR) | G2: 12.4 (8.7) | G2: 6.8 (7.9) (P =NR) | G2: 62.8 (10.9) | G2: NR
The Toronto Hospital, Outpatient, Canada | | Enrollment: | Sex: | Wt < 85% or > 125% of statistical avg for age and height; use of any psychotropic meds in the preceding 4 wks; presence of suicidal ideation, substance abuse or medical instability (including aserum potassium of < 3 μmol/liter). | | | No | (P= NS) | Diff between groups (P= NS) | (P= NS) | Diff between groups (P= NS) | (P= NS) | Diff between groups (P= NS)
Enrollment period: | | - 110 women screened and 38 enrolled.; - All participants completed single-blind placebo phase during which binge eating and vomiting episodes recorded.; - Individuals who reported fewer than 3 binge episodes a wk or experienced a 50% reduction in binge frequency were removed from study.; - 2 participants dropped during the single blind washout phase.; - 4 dropped out of each tx group after 4 wks | Female: 100% | | | | Blinding: | | Diff between groups in change over time (P =NS) | | Diff between groups in change over time (P =NS) | | Diff between groups in change over time (P =NR)
NR | | | Race/ethnicity: | | | | Double | | | | | | Change in Wt (%):
| | | NR | | | | Adverse events: | | | | | | > 1 kg wt loss:
| | | Duration of illness, yrs, mean (SD): | | | | 2 individuals in G1 experienced intolerable side effects (nausea) and dropped out and 1 individual from G2 reported headaches and dropped out. Common side effects included sleepdisturbance, nausea and dizziness among G1 participants. Headache, dry mouth, and nausea were common side effects for G2. | | | | | | G1: 53%
| | | G1: 14.3 (15.3) | | | | Funding: | | | | | | G2: 12%
| | | G2: 13.8 (10.1) | | | | Ciba-Geigy Canada and Ontario Mental Health Foundation | | | | | | Diff between groups (P= NR)
| | | Diagnostic comorbidity, %: | | | | | | | | | | G1 better than G2
| | | Major Depression: | | | | | | | | | | > 1 kg wt gain:
| | | Current: | | | | | | | | | | G1: 32%
| | | G1: 26% | | | | | | | | | | G2: 53%
| | | G2: 24% | | | | | | | | | | Diff between groups (P= NR)
| | | Past: | | | | | | | | | | G1 better than G2
| | | G1: 63% | | | | | | | | | | Chi-square (P< 0.05)
| | | G2: 47% | | | | | Vomiting episodes/wk, mean (SD): | Vomiting episodes/wk, mean (SD): | HAM-A, mean (SD): | HAM-A, mean (SD): | BMI, kg/m2, mean (SD): | BMI, kg/m2, mean (SD):
| | | Dysthymic Disorder: | | | | | G1: 10.2 (12.9) | G1: 2.6 (3.0) (P =NR) | G1: 13.4 (7.9) | G1: 7.6 (7.8) (P =NR) | G1: 26.2 (6.5) | G1: NR
| | | Current: | | | | | G2: 7.5 (6.5) | G2: 5.7 (6.3) (P =NR) | G2: 11.3 (8.8) | G2: 5.9 (6.7) (P =NR) | G2: 24.2 (4.8) | G2: NR
| | | G1: 5% | | | | | (P= NS) | Diff between groups (P< 0.02) | (P= NS) | Diff between groups (P= NS) | (P= NS)
| | | G2: 6% | | | | | | G1 better than G2 | | Diff between groups in change over time (P =NS)
| | | Past: | | | | | | Diff between groups in change over time (P =NS)
| | | G1: 5% | | | | | Non-binge meals/wk, mean (SD): | Non-binge meals/wk, mean (SD):
| | | G2: 12% | | | | | G1: 8.8 (6.9) | G1: 11.6 (6.5) (P =NR)
| | | Substance abuse: | | | | | G2: 14.1 (5.5) | G2: 17.9 (2.7) (P =NR)
| | | Current: | | | | | (P< 0.02) | Diff between groups (P= NS)
| | | G1: 0 | | | | | | Diff between groups in change over time (P <0.04)
| | | G2: 0 | | | | | | G2 better than G1 at wk 8 only
| | | Past: | | | | | EAT-26, mean (SD): | EAT-26, mean (SD):
| | | G1: 21% | | | | | G1: 36.5 (12.4) | G1: 24.4 (15.3) (P =NR)
| | | G2: 18% | | | | | G2: 34.6 (14.9) | G2: 23.9 (15.0) (P =NR)
| | | Panic with Agoraphobia: | | | | | (P= NS) | Diff between groups (P= NS)
| | | Current: | | | | | | Diff between groups in change over time (P =NS)
| | | G1: 0 | | | | | EDI-Body Dissatisfaction, mean (SD): | EDI-Body Dissatisfaction, mean (SD):
| | | G2: 0 | | | | | G1: 18.4 (9.2) | G1: 19.5 (9.9) (P =NR)
| | | Past: | | | | | G2: 19.4 (9.6) | G2: 18.3 (9.6) (P =NR)
| | | G1: 5% | | | | | (P= NS) | Diff between groups (P= NS)
| | | G2: 12% | | | | | | Diff between groups in change over time (P =NS)
| | | Panic without Agoraphobia: | | | | | EDI-Bulimia, mean (SD): | EDI-Bulimia, mean (SD):
| | | Current: | | | | | G1: 14.3 (4.8) | G1: 5.9 (5.9) (P =NR)
| | | G1: 0 | | | | | G2: 13.6 (3.3) | G2: 7.9 (5.3) (P =NR)
| | | G2: 12% | | | | | (P= NS) | Diff between groups (P= NS)
| | | Past: | | | | | | Diff between groups in change over time (P =NS)
| | | G1: 0 | | | | | EDI-Drive for thinness, mean (SD): | EDI-Drive for thinness, mean (SD):
| | | G2: 12% | | | | | G1: 15.7 (4.6) | G1: 13.5 (6.1) (P =NR)
| | | Generalized Anxiety: | | | | | G2: 14.4 (6.2) | G2: 12.4 (5.9) (P =NR)
| | | Current: | | | | | (P= NS) | Diff between groups (P= NS)
| | | G1: 5% | | | | | | Diff between groups in change over time (P =NS)
| | | G2: 0
| | | Past: | | | | | | Abstinence from vomiting, %:
| | | G1: 0 | | | | | | Wk 4:
| | | G2: 0 | | | | | | G1: 56%
| | | Social Anxiety: | | | | | | G2: 27%
| | | Current: | | | | | | End of tx:
| | | G1: 11% | | | | | | G1: 44%
| | | G2: 0 | | | | | | G2: 20%
| | | Past: | | | | | | (P= NS)
| | | G1: 11% | | | | | | Abstinence from bingeing, %:
| | | G2: 0 | | | | | | Wk 4:
| | | Simple phobia: | | | | | | G1: 31%
| | | Current: | | | | | | G2: 7%
| | | G1: 16% | | | | | | End of tx:
| | | G2: 0 | | | | | | G1: 19%
| | | Past: | | | | | | G2: 13%
| | | G1: 11% | | | | | | (P= NS)
| | | G2: 0%
| | | Obsessive-compulsive disorder:
| | | Current:
| | | G1: 0
| | | G2: 6%
| | | Past:
| | | G1: 0
| | | G2: 6%
| | | Somatoform pain disorder:
| | | Current:
| | | G1: 0
| | | G2: 6%
| | | Past:
| | | G1: 0
| | | G2: 0
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | 2 wk placebo wash out. Randomized to trazodone (50 mg) or placebo and instructed to raise the dose by 1 tablet every second day to a max of 8 tablets (trazodone 400 mg). Allowed to raise dose more slowly or take ≤ 8 if side effects. | Wilcoxon rank sum, 2-tailed for frequency fx of binge eating between groups. Diff. in proportions between groups assessed by Fisher's exact test, 2-tailed. | Score: | Current frequency of binges/wk: | Current frequency of binges/wk: | | | | No relation between blood trazodone plasma levels and degree of clinical improvement. Data NR
Pope et al., 1989 | To assess the efficacy of trazodone compared to placebo and its adverse effects in BN | G1: Trazodone (N = 23) | Total sample: 26.0 | DSM III-R criteria for BN (at least 3 binge episodes per wk and duration of 3 mos, as opposed to 2 per wk and for only 3 mos); age: 18–55; wt between 80% and 140% of IBW; use of vomiting as principal method of purging | 6 wks of active drug phase and seen at wks 2, 4, 6. Assessment at baseline and wk 6 | | Fair | G1: 11.3 | G1: data in graph (P < 0.05)
Setting: | | G2: Placebo (N = 23) | G1: 25.7 (N = 20) | Exclusion: | | | Intent to treat: | G2: 12.8 | G2: data in graph (P = NS)
Outpatients of a teaching hospital in the USA | | Enrollment: | G2: 26.2 (N = 22) | No sig medical disorder; pregnant, at risk for pregnancy, nursing; taking meds with psychotropic effects; psych med within 14 days of baseline; investigational meds within 28 days of baseline; active suicidal ideation, current drug/alcohol abuse, psychotic symptoms; hx of drug hypersensitivity; hx of failure to respond to an adequate trial of antidepressants or ECT; starting any other non-pharmacological therapy within 2 mo before or after baseline. | | | No | (P = NS) | % change in Binge Eating:
Enrollment period: | | - 56 recruited and entered 2 wk placebo washout period; - 10 eliminated during placebo period (5 drop outs, 1 reduced sx, 1 sickness, 3 lab abnormalities); - 46 randomized (N = 23 each condition); - 42 completed at least 4 wks of tx; - G1 (N = 20) (1 hospitalized for alcohol dependence, 2 did not return after baseline); - G2 (N = 22) (1 developed medical condition and was withdrawn_; - 5 terminated on or after wk 4 and termination scores were based on 14-day period before termination day | (P = NS) | | | | Blinding: | | G1: 31% reduction
NR | | | Sex: | | | | Double | | G2: 21% increase
| | | Female: 100% | | | | Adverse events: | | Diff between groups (P < 0.001)
| | | Race/ethnicity: | | | | Sig more patients on trazodone than on placebo suffered dizziness, 29% vs. 4% (P = 0.042) and drowsiness, 52% vs. 17% (P = 0.025) | | G1 better than G2
| | | NR | | | | Funding: | | Remission of Binge Eating, N (%):
| | | % IBW, mean: | | | | Bristol-Myers Pharmaceuticals and NIMH | | G1: 2 (10%)
| | | Total: 98.3 | | | | | | G2: 0
| | | G1: 98.4 | | | | | | (P = NR)
| | | G2: 98.2 | | | | | Current frequency of vomiting/wk: | Current frequency of vomiting/wk: | HAM-D (mean): | HAM-D:
| | | (P = NS) | | | | | G1: NR | G1: data in graph (P < 0.05) | Total sample: 12.4 | G1: NR (P = NR)
| | | Duration of bulimic symptoms, yrs, mean: | | | | | G2: NR | G2: data in graph (P = NS) | G1: NR | G2: NR (P = NR)
| | | Total: 7.4 | | | | | (P = NR) | % change in vomiting frequency: | G2: NR | Diff between groups (P = NS)
| | | G1: 6.8 | | | | | | G1: NR
| | | G2: 7.9 | | | | | | G2: NR
| | | (P = NS) | | | | | | Diff between groups (P < 0.001)
| | | SCID Current major depression, N: | | | | | | G1 better than G2
| | | Total: 10 (24%, 3 of which were bipolar) | | | | | | Self-Report measures: | HAM-A (mean): | HAM-A:
| | | G1: 6 | | | | | | Fear of Eating: | Total sample: 9.8 | G1: NR (P = NR)
| | | G2: 4 | | | | | | G1: NR (P < 0.05) | G1: NR | G2: NR (P = NR)
| | | SCID Hx of AN, N: | | | | | | G2: NR (P = NS) | G2: NR | Diff between groups (P = NS)
| | | Total: 6 | | | | | | Diff between groups (P = 0.007)
| | | | | | | | | G1 better than G2
| | | | | | | | | Self-control:
| | | | | | | | | G1: NR (P = NR)
| | | | | | | | | G2: NR (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Self-esteem:
| | | | | | | | | G1: NR (P = NR)
| | | | | | | | | G2: NR (P = NR)
| | | | | | | | | Diff between groups (P = 0.009)
| | | | | | | | | Global Improvement:
| | | | | | | | | G1: NR (P = NR)
| | | | | | | | | G2: NR (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Preoccupation with food:
| | | | | | | | | Data NR
| | | | | | | | | G1 = G2
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Intensity of binges:
| | | | | | | | | G1: NR (P = NR)
| | | | | | | | | G2: NR (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Self-control regarding food:
| | | | | | | | | G1: NR (P = NR)
| | | | | | | | | G2: NR (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | Patient-rating of effectiveness of tx (4 patient Likert scale):
| | | | | | | | | | | G1: NR (P = NR)
| | | | | | | | | | | G2: NR (P = NR)
| | | | | | | | | | | Diff between groups (P = 0.04)
| | | | | | | | | | | G1 better than G2
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | After one-wk of no-therapy screening, patients assigned to acute, single blind tx with 60 mg/day of fluoxetine. During screening and acute tx phase patients seen by the investigators each wk. Dosage adjustment allowed in first 2 wks at clinician's discretion if patient unable to tolerate 60 mg initially. To be considered a “tx responder” at the end of acute period, patients must have experienced a decrease of ≥ 50% in frequency of vomiting episodes during at least 1 of 2 preceding wks compared to baseline. | Time to relapse curves estimated for each tx group and a two sided log rank test used to compare time to relapse distributions. Tx diffs assessed with Fisher's exact test for categorical variables and student's t test for continuous variables. | Score: | Vomiting episodes/wk, mean (SD): | Change in vomiting episodes/wk, mean (SD): | CGI severity score: | CGI severity mean change score (SD): | BMI: | BMI:
Romano et al., 2002 | Evaluate fluoxetine versus placebo in preventing relapse of BN over one yr | G1: Fluoxetine (N = 76) | G1: 29.5 (7.0) | Male and female outpatients, at least 18 yrs old with a psychiatric dx of BN, purging type (as defined by DSM IV). Purging must included self-induced vomiting. | After 8 wks of acute tx, tx responders randomly assigned to receive 60 mg of fluoxetine or placebo for up to 52 wks. Study meds packaged in blister packs that contained 20 mg of fluoxetine capsules or matching placebo capsules. At each visit, patients returned the blister pack so that remaining capsules could be counted. Patients who missed meds for 5 consecutive days or who failed to attend visits within stated periods were deemed noncompliant and withdrawn from study. During 52-wk double blind therapy phase, visits occurred at 2-wk intervals during first 8 wks and at 4-wk intervals after that. The primary efficacy measure was change in the number of vomiting episodes per wk. | | Fair | G1: 12.1 (8.7) | G1: 2.92 (7.08) | G1: 4.5 (0.6) | G1: 0.45 (1.33) | G1: 22.5 (3.9) | G1: NR
Setting: | | G2: Placebo (N = 74) | G2: 30.0 (9.3) | Exclusion: | | | Intent to treat: | G2: 14.0 (11.7) | G2: 4.82 (8.43) | G2: 4.5 (0.7) | G2: 0.97 (1.21) | G2: 23.0 (3.8) | G2: NR
16 sites in USA (NY, MA, CA, MD, IL, NM, UT, NC, TN, PA, FL, WI, KS); Outpatient, USA | | Enrollment: | (P = NS) | Participated in a prior fluoxetine study or taken fluoxetine within 5 wks before enrollment or previously treated with 60 mg/day of fluoxetine for longer than 8 wks. Co-existing schizophrenia or bipolar disorder, mood-congruent or incongruent psychotic features, serious suicidal risk, organic brain disease, hx of seizures, medically unstable condition or hx of an alcohol and/or other substance abuse disorder within 3 mos before enrollment. Also, patients who had used a monoamine oxidase inhibitor within 2 wks before enrollment had used other investigational drugs or psychoactive meds within 4 wks before enrollment had received CBT within 4 wks of enrollment or who planned to begin a structured, focused therapy at any time during the study were excluded. | | | Yes | (P = NS) | Diff over time (P = NR) | (P = NS) | Diff over time (P = NR) | (P = NS) | Diff over time (P = NR)
Enrollment period: | | - 265 in initial screening; - 1 wk no-therapy screening phase; - 232 received single-blind acute therapy (60 mg/day of fluoxetine); - After 8 wks of acute tx, 150 responders randomly assigned to 60 mg/day of fluoxetine or placebo (doubleblind therapy); - Nonresponders and patients unable to tolerate 60 mg/day were discontinued | Sex: | | | | Blinding: | Vomiting episodes/wk at random assignment, mean (SD): | Diff between groups (P = NR) | CGI severity at random assignment: | Diff between groups (P = NR) | BMI at random assignment: | Diff between groups (P = NR)
NR | | | Female: | | | | Double | G1: 4.1 (5.5) | Diff between groups in change over time (P < 0.001) | G1: 2.9 (1.0) | Diff between groups in change over time (P < 0.004) | G1: NR | Diff between groups in change over time (P = NS)
| | | G1: 97% | | | | Adverse events: | G2: 4.5 (6.1) | G1 better than G2 (less increase after random assignment) | G2: 2.9 (0.9) | G1 deteriorated less than G2 | G2: NR
| | | G2: 98.6% | | | | Rhinitis: | (P = NS) | | (P = NS) | CGI Improvement severity mean change score (SD): | (P = NR)
| | | (P = NS) | | | | G1: 31.6% | | | | G1: 0.77 (1.43)
| | | Race/ethnicity: | | | | G2: 16.2% | | | | G2: 1.37 (1.39)
| | | Caucasian: | | | | (P < 0.04) | | | | Diff over time (P = NR)
| | | G1: 93% | | | | Unwanted Pregnancy: | | | | Diff between groups (P = NR)
| | | G2: 88% | | | | G1: 2.6% | | | | Diff between groups in change over time (P < 0.009)
| | | (P = NS) | | | | G2: 4.1% | | | | G1 deteriorated less than G2
| | | | | | | (P = NR) | Binge eating episodes/wk, mean (SD): | Change in Binge eating episodes/wk, mean (SD): | HDRS: | HDRS mean change score (SD):
| | | | | | | Funding: | G1: 10.3 (7.7) | G1: 2.47 (6.58) | G1: 10.5 (6.1) | G1: 2.03 (5.66)
| | | | | | | Eli Lilly and Co. | G2: 12.5 (10.1) | G2: 4.11 (6.70) | G2: 10.5 (5.9) | G2: 3.23 (6.60)
| | | | | | | | (P = NS) | Diff over time (P = NR) | (P = NS) | Diff over time (P = NR)
| | | | | | | | Binge eating episodes/wk at random assignment, mean (SD): | Diff between groups (P = NR) | HDRS at random assignment: | Diff between groups (P = NR)
| | | | | | | | G1: 3.0 (4.8) | Diff between groups in change over time (P < 0.02) | G1: 4.6 (3.9) | Diff between groups in change over time (P = NS)
| | | | | | | | G2: 3.9 (5.1) | G1 better than G2 (less increase after random assignment) | G2: 6.1 (5.3)
| | | | | | | | (P = NS) | | (P = NS)
| | | | | | | | EDI total, mean (SD): | Change in EDI total, mean (SD): | | Patient's global impression mean change score (SD):
| | | | | | | | G1: 76.6 (26.9) | G1: 7.79 (25.49) | | G1: 0.72 (1.54)
| | | | | | | | G2: 78.4 (29.9) | G2: 17.41 (24.45) | | G2: 1.37 (1.49)
| | | | | | | | (P = NS) | Diff over time (P = NR) | | Diff over time (P = NR)
| | | | | | | | EDI total at random assignment, mean (SD): | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | | | | | | G1: 37.0 (22.0) | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P < 0.03)
| | | | | | | | G2: 39.1 (27.2) | | | G1 deteriorated less than G2
| | | | | | | | (P = NS)
| | | | | | | | | Relapse rate, %:
| | | | | | | | | 3 mos:
| | | | | | | | | G1: 19%
| | | | | | | | | G2: 37%
| | | | | | | | | Diff between groups (P < 0.04)
| | | | | | | | | G1 better than G2
| | | | | | | | | 6 mos:
| | | | | | | | | G1: 29%
| | | | | | | | | G2: 43%
| | | | | | | | | (P = NS)
| | | | | | | | | 12 mos:
| | | | | | | | | G1: 33%
| | | | | | | | | G2: 51%
| | | | | | | | | (P = NS)
| | | | | | | | | Two sided log rank test applied to Kaplan-Meier survival function (P < 0.02)
| | | | | | | | | G1 better than G2
| | | | | | | | | Abstinence/Remission:
| | | | | | | | | NR
| | | | | | | | Yale-Brown Cornell ED Scale (YBC-EDS) score, mean (SD): | Change in YBC EDS, mean (SD):
| | | | | | | | G1: 18.8 (4.1) | G1: 2.92 (7.91)
| | | | | | | | G2: 18.3 (5.1) | G2: 7.38 (6.80)
| | | | | | | | (P = NS) | Diff over time (P = NR)
| | | | | | | | YBC EDS at random assignment, mean (SD): | Diff between groups (P = NR)
| | | | | | | | G1: 9.4 (4.8) | Diff between groups in change over time (P < 0.002)
| | | | | | | | G2: 9.4 (5.4) | G1 better than G2 (less increase after random assignment)
| | | | | | | | (P = NS) | Change in YBC EDS preoccupation, mean (SD):
| | | | | | | | | G1: 1.53 (3.82)
| | | | | | | | | G2: 3.63 (3.74)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.008)
| | | | | | | | | G1 better than G2 (less increase after random assignment)
| | | | | | | | | Change in YBC EDS ritual, mean (SD):
| | | | | | | | | G1: 1.35 (4.51)
| | | | | | | | | G2: 3.75 (3.79)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.008)
| | | | | | | | | G1 better than G2 (less increase after random assignment)
Author, yr: | Research objective: | Groups: | Age, yrs, mean: | Inclusion: | Initial dose of flutamide (250 mg/day) and citalopram (20mg/day) titrated within 2 wks to final doses of 500 mg/day and 40 mg/day, respectively. Subjects received no formal psychotherapy; supportive and educative therapy kept to a min. Tx lasted for 12 wks. | T-tests were used to evaluate within-group changes in symptom severity from baseline to end of tx. 2-sided Mann-Whitney U tests used to compare global effect of tx vs placebo on change in BN symptoms. | Score: | BN symptom VAS, mean (SD): | BN symptom VAS, mean (SD): | | Global Rating of Sadness:
Sundblad et al., 2005 | Comparison of efficacy of four txs for BN: flutamide (androgen antagonist) vs citalopram (SSRI) vs combination of flutamide and citalopram, vs placebo. | G1: Flutamide (N = 9) | G1: 29 | DSM IV criteria for for BN, purging type, irregular menstruation allowed | | | Poor | G1: 52.0 (16.0) | G1: 29.5 (27.2) (P = 0.04) | | G1: NR
Setting: | | G2: Citalopram (N = 15) | G2: 26 | Exclusion: | | | Intent to treat: | G2: 54.1 (13.9) | G2: 31.6 (22.6) (P = 0.003) | | G2: NR
Single center | | G3: Flutamide + Citalopram (N = 10) | G3: 25 | Age ≤ 18 yrs; other mental disorders | | | Yes | G3: 44.5 (10.4) | G3: 26.4 (16.3) (P = 0.005) | | G3: NR
Outpatient, Sweden | | G4: Placebo (N = 12) | G4: 28 | | | | Blinding: | G4: 52.3 (17.2) | G4: 46.9 (21.9) (P = NS) | | G4: NR
Enrollment period: | | Enrollment: | Sex: | | | | Double | (P = NR) | Diff between groups | | Diff between groups (P = NR)
NR | | - Individuals recruited through advertisements; - Patients randomized to one of 4 conditions once consent obtained; - Dropouts during tx (G1 = 3; G2 = 3; G3 = 2; G4 = 2) | Female: 100% | | | | Adverse events: | | G1, G2, G3 vs. G4 (P = NR) | | Diff between groups in change (reduction) over time (P < 0.05)
| | | Race/ethnicity: | | | | 2 cases of elevated serum aminotrans-ferase in flutamide-tx group; both normalized after tx withdrawal. Nausea most common side effect for citalopram; dry skin most common for flutamide participants. | | G1+G3 < G4 (P = 0.03) | | G2 and G3 better than G4
| | | NR | | | | Funding: | | G2+G3 < G4 (P = 0.03) | | G2 vs G4 (P = NS)
| | | Wt, kgs, mean: | | | | H Lundbeck AB, Sweden and Swedish Medical Research Council | | Diff between groups in change over time (P = NR) | | Global Rating of Anxiety:
| | | G1: 58 | | | | | | % reduction BN VAS, mean (SD): | | G1: NR
| | | G2: 61 | | | | | | G1: 46 (15) (P = NR) | | G2: NR
| | | G3: 61 | | | | | | G2: 41 (12) (P = NR) | | G3: NR
| | | G4: 61 | | | | | | G3: 41 (11) (P = NR) | | G4: NR
| | | | | | | | | G4: 8 (10) (P = NR) | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups | | Diff between groups in change (reduction) over time (P < 0.05)
| | | | | | | | | G1, G3 > G4 (P = 0.04) | | G2 and G3 better than> G4
| | | | | | | | | G1+G3 < G4 (P = 0.02) | | G2 vs G4 (P = NS)
| | | | | | | | | G2+G3 < G4 (P = 0.03)
| | | | | | | | Binge eating episodes per wk, mean (SD): | Binge eating episodes per wk (SD):
| | | | | | | | G1: 6.1 (1.8) | G1: 3.0 (3.0) (P = 0.01)
| | | | | | | | G2: 6.6 (3.4) | G2: 4.9 (3.9) (P = NS)
| | | | | | | | G3: 6.4 (2.1) | G3: 2.9 (2.0) (P = 0.0007)
| | | | | | | | G4: 8.0 (3.8) | G4: 6.7 (5.9) (P = NS)
| | | | | | | | (P = NR) | Diff between groups
| | | | | | | | | G1, G2, G3 vs. G4 (P = NR)
| | | | | | | | | G1+G3 < G4 (P = 0.02)
| | | | | | | | | G2+G3 < G4 (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | % reduction binge episodes, mean (SD):
| | | | | | | | | G1: 54 (40) (P = NR)
| | | | | | | | | G2: 21 (88) (P = NR)
| | | | | | | | | G3: 54 (28) (P = NR)
| | | | | | | | | G4: 15 (47) (P = NR)
| | | | | | | | | Diff between groups
| | | | | | | | | G3 > G4 (P = 0.04)
| | | | | | | | | G1, G2 (P = NS)
| | | | | | | | | G1+G3 < G4 (P = 0.01)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Vomiting episodes, per wk, mean (SD): | Vomiting episodes per wk, mean (SD):
| | | | | | | | G1: 8 (4) | G1: 4 (4) (P = 0.01)
| | | | | | | | G2: 9 (7) | G2: 6 (6) (P = NS)
| | | | | | | | G3: 7 (3) | G3: 3 (3) (P = 0.0007)
| | | | | | | | G4: 9 (3) | G4: 7 (5) (P = NS)
| | | | | | | | (P = NR) | Diff between groups
| | | | | | | | | G1, G2, G3 vs. G4 (P = NR)
| | | | | | | | | G1+G3 < G4 (P = NS)
| | | | | | | | | G2+G3 < G4 (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | % reduction vomiting episodes, mean (SD):
| | | | | | | | | G1: 45 (56) (P = NR)
| | | | | | | | | G2: 28 (46) (P = NR)
| | | | | | | | | G3: 52 (36) (P = NR)
| | | | | | | | | G4: 31 (37) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | BN symptom improvement, %:
| | | | | | | | | G1: Enormously (22%), Much (22%), Somewhat (33%), No change (11%), Deterioration (11%)
| | | | | | | | | G2: Enormously (20%), Much (20%), Somewhat (33%), No change (27%), Deterioration (0%)
| | | | | | | | | G3: Enormously (10%), Much (40%), Somewhat (20%), No change (20%), Deterioration (10%)
| | | | | | | | | G4: Enormously (0%), Much (8%), Somewhat (17%), No change (50%), Deterioration (25%)
| | | | | | | | | Global BN symptom change vs. placebo, Mann-Whitney U:
| | | | | | | | | G1: 23.5 (P = 0.03)
| | | | | | | | | G2: 35.5 (P = 0.008)
| | | | | | | | | G3: 28.5 (P = 0.04)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | During the first wk of tx, dose of desipramine gradually raised to 200 mg/day (four 50 mg tablets) or the equivalent dose of placebo. If tolerated, this dose was continued for three wks. Four wks after randomization, patients who continued to binge eat had dose raised to 300 mg/day. Tx lasted for 6 wks. After the 6 wk tx, patients who had been randomly assigned to placebo and had not improved were offered open trial of desipramine. | Student's t test was used to compare groups. | Score: | Binge episodes/wk, mean (SD): | Binge episodes/wk, mean (SD): | HAM-D, mean (SD): | HAM-D, mean (SD): | BMI, mean (SD) kg/m^2^: | BMI, mean (SD) kg/m^2^:
Walsh et al., 1991 | Compare antidepressant desipramine with placebo in treating BN and examine long-term efficacy of drug. | G1: placebo (N = 38) | G1: 25.7 (5.6) | DSM III-R criteria for BN for at least 1 yr, only women between the ages of 18 and 45 whose wt was 85%-120% of their IBW (according to Metropolitan Life Insurance Company tables) | To enter the maintenance phase, patients required to have achieved reduction of 50% or more in binge frequency in the last two wks of the tx phase compared to baseline. Patients who met this criterion were continued on desipramine for another 16 wks. | | Fair | G1: 8.3 (5.4) | G1: 8.6 (7.2) (P = NR) | G1: 7.3 (4.6) | G1: 6.5 (5.1) (P = NR) | G1: 22.0 (2.3) | G1: 22.3 (2.5) (P = NR)
Setting: | | G2: desipramine (N = 40) | G2: 24.8 (4.5) | Exclusion: | Patients who had not relapsed during maintenance phase, offered to participate in the discontinuation phase. Here patients randomly assigned to either continue taking the same dose of meds or switch to placebo. Meds tapered to placebo over two wks. | | Intent to treat: | G2: 8.1 (4.6) | G2: 4.3 (3.9) (P = NR) | G2: 8.3 (4.6) | G2: 6.0 (4.7) (P = NR) | G2: 22.4 (1.9) | G2: 22.0 (1.9) (P = NR)
Outpatient, New York, USA | | Enrollment: | (P = NS) | Acute or chronic medical conditions; judged to be acutely suicidal; currently being treated with psychotropic meds; had abused drugs or alcohol in the past yr or had previous adequate trial of antidepressant meds (min of 200 mg of desipramine for at least 3 wks or equivalent meds doses). | | | Used termination data for those who completed initial 6 wks and those who discontinued before initial 6 wks. | (P = NS) | Diff between groups (P < 0.001) | (P = NS) | Diff between groups (P = NS) | (P = NS) | Diff between groups (P = 0.001)
Enrollment period: | | - 217 individuals had screening interviews; - 98 entered study (56 did not meet entry criteria, 46 refused and 17 who did not FU after screening); - Patients first entered into a 2-wk single-blind placebo washout phase; - 10 patients dropped after washout phase because they had reduced binge eating by 75% or more or were binge eating less than twice a wk.; - 8 patients dropped out.; - 80 patients entered the double-blind trial.; - Completers:; - 2 patients did not return after assignment and are not included in analyses; - G1: 32/38; - G2: 31/40 | Height, inches, mean (SD): | | | | Blinding: | | G2 better than G1 | | Diff between groups in change over time (P = NR) | | G2 better than G1
NR | | | G1: 65.0 (2.7) | | | | Initially participants were in a single blind washout phase and the tx component was double blinded. | | Diff between groups in change over time (P = NR) | | | | Diff between groups in change over time (P = NR)
| | | G2: 65.4 (2.1) | | | | Adverse events: | Vomiting episodes/wk, mean (SD): | Vomiting episodes/wk, mean (SD): | BDI, mean (SD): | BDI, mean (SD):
| | | (P = NS) | | | | NR | G1: 13.0 (16.7) | G1: 13.3 (17.5) (P = NR) | G1: 15.0 (11.1) | G1: 13.0 (11.0) (P = NR)
| | | Wt, lbs, mean (SD): | | | | Funding: | G2: 10.8 (12.7) | G2: 7.8 (14.4) (P = NR) | G2: 10.4 (7.3) | G2: 9.2 (7.7) (P = NR)
| | | G1: 132.4 (17.8) | | | | NIMH | (P = NS) | Diff between groups (P = 0.02) | (P = 0.04) | Diff between groups (P = NS)
| | | G2: 136.2 (16.1) | | | | | | G2 better than G1 | | Diff between groups in change over time (P = NR)
| | | (P = NS) | | | | | | Diff between groups in change over time (P = NR)
| | | Sex: | | | | | Eating Attitudes Test, mean (SD): | Eating Attitudes Test, mean (SD): | SCL-90 Global Symptom index, mean (SD): | SCL-90 Global Symptom index, mean (SD):
| | | Female: | | | | | G1: 39.6 (15.2) | G1: 37.7 (15.1) (P = NR) | G1: 2.1 (0.7) | G1: 2.0 (0.7) (P = NR)
| | | G1: 100% | | | | | G2: 39.8 (16.9) | G2: 29.9 (16.0) (P = NR) | G2: 1.9 (0.5) | G2: 1.6 (0.4) (P = NR)
| | | G2: 100% | | | | | (P = NS) | Diff between groups (P = 0.03) | (P = NS) | Diff between groups (P = 0.009)
| | | (P = NS) | | | | | | G2 better than G1 | | G2 better than G1
| | | Race/ethnicity: | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | NR | | | | | Body Shape Questionnaire, mean (SD): | Body Shape Questionnaire, mean (SD): | SCL-90 Anxiety scale, mean (SD): | SCL-90 Anxiety scale, mean (SD):
| | | BMI, kg/m^2^, mean (SD): | | | | | G1: 135.3 (28.3) | G1: 120.5 (34.2) (P = NR) | G1: 2.0 (0.8) | G1: 1.9 (0.8) (P = NR)
| | | G1: 22.0 (2.3) | | | | | G2: 148.7 (35.6) | G2: 101.6 (36.6) (P = NR) | G2: 1.9 (0.6) | G2: 1.7 (0.6) (P = NR)
| | | G2: 22.4 (1.9) | | | | | (P = NS) | Diff between groups (P = 0.02) | (P = NS) | Diff between groups (P = NS)
| | | (P = NS) | | | | | | G2 better than G1 | | Diff between groups in change over time (P = NR)
| | | Duration of illness, yrs, mean (SD): | | | | | | Diff between groups in change over time (P = NR)
| | | G1: 6.6 (4.5) | | | | | | Remission rate: | SCL-90 Depression scale, mean (SD): | SCL-90 Depression scale, mean (SD):
| | | G2: 6.7 (3.6) | | | | | | G1: 7.9% | G1: 2.5 (1.0) | G1: 2.5 (0.9) (P = NR)
| | | (P = NS) | | | | | | G2: 12.5% | G2: 2.3 (0.8) | G2: 1.9 (0.7) (P = NR)
| | | Hx of AN: | | | | | | Diff between groups (P = NS) | (P = NS) | Diff between groups (P = 0.007)
| | | 23.10% | | | | | | | | G2 better than G1
| | | Current Depression: | | | | | | | | Diff between groups in change over time (P = NR)
| | | 51.30% | | | | | | | SCL-90 | SCL-90
| | | | | | | | | | Obsessive/Compulsive scale, mean (SD): | Obsessive/Compulsive scale, mean (SD):
| | | | | | | | | | G1: 2.2 (1.0) | G1: 2.1 (1.0) (P = NR)
| | | | | | | | | | G2: 2.0 (0.7) | G2: 1.6 (0.6) (P = NR)
| | | | | | | | | | (P = NS) | Diff between groups (P = 0.003)
| | | | | | | | | | | G2 better than G1
| | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | SCL-90 Hostility scale, mean (SD): | SCL-90 Hostility scale, mean (SD):
| | | | | | | | | | G1: 1.9 (0.9) | G1: 2.1 (1.0) (P = NR)
| | | | | | | | | | G2: 1.7 (0.8) | G2: 1.6 (0.6) (P = NR)
| | | | | | | | | | (P = NS) | Diff between groups (P = 0.02)
| | | | | | | | | | | G2 better than G1
| | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | STAI-State, mean (SD): | STAI-State, mean (SD):
| | | | | | | | | | G1: 51.5 (14.3) | G1: 49.3 (14.3) (P = NR)
| | | | | | | | | | G2: 48.1 (12.2) | G2: 45.5 (12.4) (P = NR)
| | | | | | | | | | (P = NS) | Diff between groups (P = NS)
| | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | STAI-Trait, mean (SD): | STAI-Trait, mean (SD):
| | | | | | | | | | G1: 54.3 (10.3) | G1: 54.1 (11.6) (P = NR)
| | | | | | | | | | G2: 51.9 (10.5) | G2: 46.5 (10.2) (P = NR)
| | | | | | | | | | (P = NS) | Diff between groups (P = 0.01)
| | | | | | | | | | | G2 better than G1
| | | | | | | | | | | Diff between groups in change over time (P = NR)

Evidence Table 6. Medication plus behavioral intervention trials for bulimia nervosa

| | | | | | | | Eating Related Measures | | Psychological/Psychiatric Measures | | Biomarkers
Study Description | Objective | Design | Patient Characteristics | Inclusion/Exclusion Criteria | Treatment | Statistical Methods | Quality | Baseline | Outcomes | Baseline | Outcomes | Baseline | Outcomes
Author, yr: | Research objective: | Groups (N = 71): | Age, yrs, mean (SD): | Inclusion: | Participants randomized to one of 5 groups: desipramine continued for 16 or 24 wks; individual CBT; combined CBT with drug tx for 16 or 24 wks. | Two primary (binge and purge frequencies) and 5 secondary factors subjected to a repeated measures ANCOVA for three groups (med alone, CBT and combined) at 16 wks; similarly, an ANCOVA was used to assess diff between 5 groups at 32 wks for primary measures, and at 24 wks for secondary measures. Two-tailed test for sig was used throughout. When sig time X group effect found, post hoc tests carried out and Bonferroni correction applied, resulting in an adjusted sig level of P < 0.005. | Score: | Binges, past 7 days, mean (SD): | Binges, past 7 days, mean (SD): | | | Wt (kg): | Wt (kg):
Agras et al., 1992 | To assess the efficacy of desipramine, CBT and their combination in the tx of women with BN. | G1: desipramine, 16 wks (N = 12) | 29.6 (8.9) | Age 18–65; met DSM III-R criteria for BN; no concurrent medical condition that would preclude use of antidepressants; no evidence of conduction disturbance on ECG | For individuals randomized to drug tx, dose began at 25 mg/day for 3 days, increased by 50 mg increments every 3–5 days to a max of 300 mg, response-contingent. At 6 wks, serum levels assessed, drug increased to 350 mg/day, as needed. | | Fair | G1: 5.5 (4.6) | 16 wks: | | | G1: NR | 32 wks
Companion article: | | G2: desipramine, 24 wks (N = 12) | Sex: | Exclusion: | Participants seen wkly for first 4 wks, then at wks 6, 8, 12, 16 (for those withdrawn per tx), then 18, 20, 24, for those continuing, per tx group. | | Intent to treat: | G2: 5.9 (5.1) | G1: 3.5 (6.1) (P = NR) | | | G2: NR | G1: NR
Agras, Rossiter et al., 1994 | | G3: desipramine, 16 wks, plus CBT (N = 12) | Female: 100% | Current AN, drug or alcohol abuse, psychosis, or depression with suicidal risk of sufficient severity to preclude use of antidepressants on an outpatient basis. | CBT was administered in 15, individual, 50 min, wkly sessions, and FU included sessions at wks 20, 24 and 28. | | Yes, for analysis of primary outcomes; secondary analyses used “completers” only. | G3: 7.5 (3.4) | G2: 3.4 (3.5) (P = NR) | | | G3: NR | G2: NR
Setting: | | G4: desipramine, 24 wks, plus CBT (N = 12) | Race/ethnicity: | | Assessments were collected at baseline, wks 16 and 24; bingeing and purging frequency also assessed at wk 32. | | Blinding: | G4: 9.3 (5.8) | G3: 2.4 (3.1) (P = NR) | | | G4: NR | G3: NR
Outpatient, ED Clinic; location: Stanford, CA, USA | | G5: CBT only (N = 23) | NR | | | | N/A | G5: 8.7 (7.2) | G4: 1.7 (1.5) (P = NR) | | | G5: NR | G4: NR
Enrollment period: | | Enrollment: | Marital Status (%): | | | | Adverse events: | (P = NS) | G5: 1.5 (2.6) (P = NR) | | | (P = NR) | G5: NR
NR | | - 100 recruited from university ED clinic and media, then interviewed; - 11 met exclusion criteria; 18 withdrew; - 71 met criteria and participated | Married: 32% | | | | “side effects” of meds reported; further detail: NR | | Diff between groups (P = NR) | | | | Diff between groups (P = NR)
| | Meds Drop-out rate: | Single: 56.3% | | | | Funding: | | Diff between groups in change over time (P < 0.005) | | | | Diff between groups in change over time (P = NS)
| | - 6 wks (12.2%); - 16 wks (14.6%); - 24 wks (17%) | Divorced: 8.5% | | | | National Institute of Mental Health | | G5 better than G1+G2 (P < 0.005)
| | CBT Drop-out rate | Separated: 2.8% | | | | | | G3+G4 better than G1+G2 (P < 0.004)
| | (4.3%) | Education (%): | | | | | | 24 wks:
| | | Graduated HS: 5.6% | | | | | | G1: 3.7 (7.1) (P = NR)
| | | Completed some HS: 1.4% | | | | | | G2: 2.7 (2.8) (P = NR)
| | | Graduated college: 56% | | | | | | G3: 2.1 (2.8) (P = NR)
| | | Completed some college: 36.7% | | | | | | G4: 2.3 (4.7) (P = NR)
| | | Age of onset of BE, yrs, mean (SD): | | | | | | G5: 2.8 (5.9) (P = NR)
| | | 19.9 (5.7) | | | | | | Diff between groups (P = NR)
| | | Age of onset of purging, yrs, mean (SD): | | | | | | Diff between groups in change over time (P = NR)
| | | 20.7 (5.9) | | | | | | 32 wks:
| | | Frequency of bingeing/wk, mean (SD): | | | | | | G1: 6.2 (13.7) (P = NR)
| | | 7.5 (5.7) | | | | | | G2: 3.3 (3.9) (P = NR)
| | | Frequency of purging/wk, mean (SD): | | | | | | G3: 3.2 (4.2) (P = NR)
| | | 9.2 (6.9) | | | | | | G4: 1.0 (3.0) (P = NR)
| | | Ideal wt, kg, mean (SD): | | | | | | G5: 2.5 (3.6) (P = NR)
| | | 53.7 (5.8) | | | | | | Diff between groups (P = NR)
| | | Baseline wt, kg, mean (SD): | | | | | | Diff between groups in change over time (P < 0.02)
| | | 59.9 (9.1) | | | | | | G4 better than G1 (P < 0.004)
| | | Prior AN Dx: | | | | | | GG4 better than G2 (P < 0.005)
| | | 22% | | | | | Purges, past 7 days, mean (SD): | Purges, past 7 days, mean (SD):
| | | | | | | | G1: 9.7 (9.4) | 16 wks:
| | | | | | | | G2: 6.3 (4.9) | G1: 4.7 (8.6) (P = NR)
| | | | | | | | G3: 8.3 (4.3) | G2: 3.9 (3.8) (P = NR)
| | | | | | | | G4: 11.7 (5.9) | G3: 2.6 (3.2) (P = NR)
| | | | | | | | G5: 10.1 (7.7) | G4: 1.2 (2.7) (P = NR)
| | | | | | | | (P = NS) | G5: 1.7 (2.7) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.004)
| | | | | | | | | G5 better than G1+G2 (P < 0.004)
| | | | | | | | | G3 better than G1+G2 (P < 0.003)
| | | | | | | | | Purges, past 7 days, mean (SD ) ( continued):
| | | | | | | | | 24 wks:
| | | | | | | | | G1: 5.0 (10.8) (P = NR)
| | | | | | | | | G2: 2.9 (3.0) (P = NR)
| | | | | | | | | G3: 2.7 (4.2) (P = NR)
| | | | | | | | | G4: 1.7 (4.7) (P = NR)
| | | | | | | | | G5: 2.7 (5.9) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 32 wks:
| | | | | | | | | G1: 6.2 (13.7) (P = NR)
| | | | | | | | | G2: 3.4 (4.1) (P = NR)
| | | | | | | | | G3: 3.2 (4.3) (P = NR)
| | | | | | | | | G4: 1.1 (3.0) (P = NR)
| | | | | | | | | G5: 2.2 (3.6) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.02)
| | | | | | | | | G4 better than G1 (P < 0.005)
| | | | | | | | Hunger/disinhibition, mean (SD): | Hunger/disinhibition, mean (SD):
| | | | | | | | G1: 10.0 (2.3) | 16 wks:
| | | | | | | | G2: 9.6 (2.3) | G1: 7.4 (2.1) (P = NR)
| | | | | | | | G3: 11.1 (2.1) | G2: 7.9 (2.7) (P = NR)
| | | | | | | | G4: 11.0 (2.1) | G3: 9.1 (3.6) (P = NR)
| | | | | | | | G5: 10.1 (3.2) | G4: 6.0 (3.4) (P = NR)
| | | | | | | | (P = NS) | G5: 8.6 (3.2) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 24 wks:
| | | | | | | | | G1: 8.7 (2.5) (P = NR)
| | | | | | | | | G2: 7.4 (1.7) (P = NR)
| | | | | | | | | G3: 11.1 (2.1) (P = NR)
| | | | | | | | | G4: 6.3 (3.2) (P = NR)
| | | | | | | | | G5: 8.3 (3.4) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.02)
| | | | | | | | | G4 better than G5 (P < 0.005)
| | | | | | | | Dietary Preoccupation, mean (SD): | Dietary Preoccupation, mean (SD):
| | | | | | | | G1: 14.0 (4.8) | 16 wks:
| | | | | | | | G2: 13.4 (5.4) | G1: 9.7 (4.5) (P = NR)
| | | | | | | | G3: 15.3 (3.0) | G2: 10.4 (6.7) (P = NR)
| | | | | | | | G4: 15.9 (3.0) | G3: 10.5 (7.1) (P = NR)
| | | | | | | | G5: 14.1 (4.3) | G4: 5.5 (2.9) (P = NR)
| | | | | | | | (P = NS) | G5: 9.3 (5.6) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.01)
| | | | | | | | | G3+G4 better than G1+G2 (P < 0.005)
| | | | | | | | | 24 wks:
| | | | | | | | | G1: 8.9 (4.1) (P = NR)
| | | | | | | | | G2: 7.5 (5.6) (P = NR)
| | | | | | | | | G3: 10.7 (7.1) (P = NR)
| | | | | | | | | G4: 5.9 (6.2) (P = NR)
| | | | | | | | | G5: 9.5 (6.0) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Abstinence from bingeing: | Abstinence from bingeing %:
| | | | | | | | NR | 16 wks:
| | | | | | | | | G1 + G2: 35%
| | | | | | | | | G3 + G4: 65%
| | | | | | | | | G5: 50%
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 24 wks: NR
| | | | | | | | | 32 wks:
| | | | | | | | | G1 + G2: 42%
| | | | | | | | | G3 + G4: 74%
| | | | | | | | | G5: 55%
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Abstinence from purging %: | Abstinence from purging:
| | | | | | | | NR | 16 wks:
| | | | | | | | | G1 + G2: 33%
| | | | | | | | | G3 + G4: 64%
| | | | | | | | | G5: 48%
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 24 wks:
| | | | | | | | | NR
| | | | | | | | | 32 wks:
| | | | | | | | | NR
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Participants randomized to one of 5 groups: desipramine continued for 16 or 24 wks; individual CBT; CBT combined with drug tx for 16 or 24 wks. | Repeated ANCOVA for 5 groups to 1 yr FU using the baseline value as the covariate. Patients descriptively classified as recovered or not recovered, defined by abstinence from both bingeing and purging for a 3-mo period. | Score: | Binges/wk, mean (SD): | Binges/wk, mean (SD): | BDI, mean (SD): | BDI, mean (SD): | NR | NR
Agras, Rossiter et al., 1994 | To assess the efficacy of desipramine, CBT and their combination in the tx of women with BN at 1 yr FU. | G1: desipramine, 16 wks | 29.6 (8.9) | Age 18–65; met DSM III-R criteria for BN; no concurrent medical condition that would preclude use of antidepressants; no evidence of conduction disturbance on ECG | For individuals randomized to drug tx, dose began at 25 mg/day for 3 days, increased by 50 mg increments every 3–5 days to a max of 300 mg, response-contingent. At 6 wks, serum levels assessed, and drug was increased to 350 mg/day, as needed. | | Fair | G1: 5.3 (6.2) | 72 wks: | G1: 15.0 (12.1) | 72 wks:
Companion article: | | G2: desipramine, 24 wks | Sex: | Exclusion: | Participants seen wkly for first 4 wks, then at wks 6, 8, 12, 16 (for those withdrawn per tx), then 18, 20, 24, for those continuing, per tx group. | | Intent to treat: | G2: 7.4 (5.4) | G1: 5.8 (10.2) (P = NR) | G2: 12.6 (10.5) | G1: 10.0 (7.5) (P = NR)
Agras et al., 1992 | | G3: desipramine, 16 wks, plus CBT | Female: 100% | Current AN, drug or alcohol abuse, psychosis, or depression with suicidal risk of sufficient severity to preclude use of antidepressants on an outpatient basis. | CBT administered in 15, individual, 50 min, wkly sessions, and FU included sessions at wks 20, 24 and 28. | | Yes, for analysis of primary outcomes; secondary analyses used “completers” only. | G3: 7.4 (3.6) | G2: 2.4 (3.6) (P = NR) | G3: 14.0 (7.7) | G2: 5.1 (5.3) (P = NR)
Setting: | | G4: desipramine, 24 wks, plus CBT | Race/ethnicity: | | Assessments collected at baseline, wks 16 and 24; bingeing and purging frequency also assessed at wk 32. | | Blinding: | G4: 7.9 (6.2) | G3: 3.4 (4.6) (P = NR) | G4: 18.6 (4.1) | G3: 9.7 (8.9) (P = NR)
Outpatient, ED Clinic; location: USA | | G5: CBT only | NR | | | | NA | G5: 8.4 (6.8) | G4: 3.1 (7.7) (P = NR) | G5: 14.3 (7.0) | G4: 4.4 (4.6) (P = NR)
Enrollment period: | | Enrollment: | Marital Status (%): | | | | Adverse events: | | G5: 2.6 (3.8) (P = NR) | (P = NR) | G5: 10.3 (13.1) (P = NR)
NR | | - 100 recruited from university ED clinic and media, then interviewed; - 71 met criteria and participated; - 11 met exclusion criteria; 18 withdrew; - 61 completed FU | Married: 32% | | | | “side effects” of meds; further detail: NR | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | Single: 56.3% | | | | Funding: | | Diff between groups in change over time (P < 0.03) | | Diff between groups in change over time (P = NR)
| | | Divorced: 8.5% | | | | National Institute of Mental Health | | G4 better than G1 (P < 0.02)
| | | Separated: 2.8% | | | | | | G5 better than G1 (P < 0.02)
| | | Education (%): | | | | | Purges/wk, mean (SD): | Purges/wk, mean (SD): | RSE, mean (SD): | RSE, mean (SD):
| | | Graduated HS: 5.6% | | | | | G1: 9.4 (10.9) | 72 wks: | G1: 3.6 (1.7) | G1: 2.6 (1.7) (P = NR)
| | | Completed some HS: 1.4% | | | | | G2: 7.8 (5.2) | G1: 5.6 (14.3) (P = NR) | G2: 3.3 (2.1) | G2: 1.8 (0.9) (P = NR)
| | | Graduated college: 56% | | | | | G3: 8.3 (4.5) | G2: 2.6 (3.6) (P = NR) | G3: 3.5 (1.7) | G3: 3.0 (1.8) (P = NR)
| | | Completed some college: 36.7% | | | | | G4: 10.0 (6.4) | G3: 3.1 (4.6) (P = NR) | G4: 3.3 (0.8) | G4: 2.0 (1.5) (P = NR)
| | | Age of onset of BE, yrs, mean (SD): | | | | | G5: 10.2 (7.5) | G4: 2.9 (5.2) (P = NR) | G5: 3.8 (1.4) | G5: 2.4 (1.9) (P = NR)
| | | 19.9 (5.7) | | | | | | G5: 2.2 (3.5) (P = NR) | | Diff between groups (P = NR)
| | | Age of onset of purging, yrs, mean (SD): | | | | | | Diff between groups (P = NR) | | Diff between groups in change over time (P = NR)
| | | 20.7 (5.9) | | | | | | Diff between groups in change over time (P = NS)
| | | Frequency of bingeing/wk, mean (SD): | | | | | | Diff between groups in change over time (P = NS)
| | | 7.5 (5.7) | | | | | Hunger/disinhibition, mean (SD): | Hunger/disinhibition, mean (SD):
| | | Frequency of purging/wk, mean (SD): | | | | | G1: 10.8 (2.6) | 72 wks:
| | | 9.2 (6.9) | | | | | G2: 10.0 (2.4) | G1: 9.5 (2.5) (P = NR)
| | | FU Ideal wt, kg, mean (SD): | | | | | G3: 11.4 (2.0) | G2: 6.3 (2.5) (P = NR)
| | | 122.8 (55.3) | | | | | G4: 10.0 (1.5) | G3: 8.8 (3.7) (P = NR)
| | | FU wt, kg, mean (SD): | | | | | G5: 10.5 (3.2) | G4: 6.1 (2.2) (P = NR)
| | | 136.5 (61.4) | | | | | | G5: 8.5 (3.5) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.01)
| | | | | | | | | G4 better than G1 (P < 0.01)
| | | | | | | | Dietary Preoccupation, mean (SD): | Dietary Preoccupation, mean (SD):
| | | | | | | | G1: 13.1 (4.4) | 72 wks:
| | | | | | | | G2: 11.2 (5.1) | G1: 8.7 (3.7) (P = NR)
| | | | | | | | G3: 15.5 (4.2) | G2: 5.1 (3.1) (P = NR)
| | | | | | | | G4: 15.3 (3.2) | G3: 9.9 (6.8) (P = NR)
| | | | | | | | G5: 14.5 (4.2) | G4: 3.2 (2.6) (P = NR)
| | | | | | | | | G5: 7.1 (5.3) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.03)
| | | | | | | | | G4 better than G1 (P < 0.001)
| | | | | | | | Restraint, mean (SD): | Restraint, mean (SD):
| | | | | | | | G1: 12.3 (5.1) | 72 wks:
| | | | | | | | G2: 11.4 (4.6) | G1: 12.6 (3.2) (P = NR)
| | | | | | | | G3: 11.2 (4.2) | G2: 11.3 (5.3) (P = NR)
| | | | | | | | G4: 13.7 (4.2) | G3: 11.9 (5.2) (P = NR)
| | | | | | | | G5: 12.0 (4.4) | G4: 12.6 (4.7) (P = NR)
| | | | | | | | | G5: 13.2 (4.5) (P = NR)
| | | | | | | | | (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Post-tx:
| | | | | | | | | Recovered, abstinence from bingeing and purging for prior 3 mos, N (%):
| | | | | | | | | G1: 5 (45%) (P = NR)
| | | | | | | | | G2: 5 (45%) (P = NR)
| | | | | | | | | G3: 5 (50%) (P = NR)
| | | | | | | | | G4: 5 (56%) (P = NR)
| | | | | | | | | G5: 9 (41%) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Not recovered, N (%)
| | | | | | | | | G1: 6 (55%) (P = NR)
| | | | | | | | | G2: 4 (44%) (P = NR)
| | | | | | | | | G3: 5 (50%) (P = NR)
| | | | | | | | | G4: 4 (44%) (P = NR)
| | | | | | | | | G5: 13 (59%) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 72-wk FU:
| | | | | | | | | Maintained Recovery, N (%):
| | | | | | | | | G1: 1/5 (20%) (P = NR)
| | | | | | | | | G2: 5/5 (100%)) (P = NR)
| | | | | | | | | G3: 4/5 (80%) (P = NR)
| | | | | | | | | G4: 5/5 (100%) (P = NR)
| | | | | | | | | G5: 7/9 (78%) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Additional recovered, N (%)
| | | | | | | | | G1: 1/6 (17%) (P = NR)
| | | | | | | | | G2: 1/4 (25%) (P = NR)
| | | | | | | | | G3: 0/5 (0%) (P = NR)
| | | | | | | | | G4: 2/4 (50%) (P = NR)
| | | | | | | | | G5: 5/13 (38%) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Assessment: Baseline, 6 wks, end of tx, 4 wk FU | Non-parametric chi square to compare sociodemographic variables. ANCOVA for 4-wk post tx symptom variables (controlling for pre-tx measures). Repeated measures MANOVA to compare change in primary and secondary psychological variables between groups. | Score: | | Note: ITT ANCOVA analyses (N = 76) found no sig diffs between groups on any measures.*** | BDI, mean (SD): | 4 Wks Post-tx: | Wt, lbs, mean (SD): | 4 Wks Post-tx:
Goldbloom et al., 1997 | To compare fluoxetine, individual CBT, and fluoxetine plus individual CBT in the tx of BN. | G1: Fluoxetine (N = 23) | 25.8 (5.5) | Female, age: 18–45; 85–125% matched population mean wt; DSM III-R dx of BN; binge and vomit at least twice per wk per EDE; min 6 mo duration of illness. | G1: Met with psychiatrist individually once per wk for 4 wks and then biwkly for 12 wks (total = 10 sessions). Sessions < 10 m and focused on meds issues. Prescribed 60 mg per day, adjusted if side effects emerged. | | Fair | | | G1: 16.3 (9.4) | BDI, mean (SD): | G1: NR | Change in wt, lbs, mean (SD):
Setting: | | G2: CBT (N = 24) | Sex: | Exclusion: | G2: Met with psychologist wkly for 16 wks. Sessions were 1 hr based on Fairburn's manual. | | Intent to treat: | | | G2: 18.4 (11.5) | G1: 13.6 (15.3) (P = NS) | G2: NR | G1: -2.0 (10.0) (P = NR)
Eating Disorders Program - Toronto Hospital, Canada - | | G3: Fluoxetine+CBT (N = 29) | Female: 100% | Ongoing pharmacotherapy or psychotherapy or use of MAOIs within 2 wks prior to the onset of study tx; immediate suicide risk or psychosis; medical contraindications to drug tx; previous exposure to research txs. | G3: Met separately with pharmacotherapists and psychotherapists as described above; involved greater frequency of professional contacts than either tx alone. | | Yes | | | G3: 14.8 (13.0) | G2: 13.8 (14.2) (P = NS) | G3: NR | G2: 5.0 (7.7) (P = NR)
Enrollment period: | | Enrollment: | Race/ethnicity: | | | | Blinding: | | | (P = NS) | G3: 7.5 (9.0) (P = NS) | (P = NR) | G3: 3.2 (7.3) (P = NR)
2 yrs | | N = 76 (approximately 13% of all initial consultations for ED conducted during the recruitment period) | NR | | | | No | | | | Diff over time (P = NS) | | Diff between groups (P = NS)
| | Completed at least 14 wks, N (%): | BMI, mean (SD): | | | | Adverse events: | | | | Diff between groups (P = NS) | | Diff between groups in change over time (P = NR)
| | G1: 14 (60.9) | 23.0 (2.5) | | | | Dropped out because of side effects, N: | | | | Diff between groups in change over time (P = NR)
| | G2: 16 (66.7) | Past highest BMI, mean (SD): | | | | G1: 4 | | At Treatment Completion: | RSE, mean (SD): | RSE, mean (SD):
| | G3: 13 (43.8) | 25.8 (3.6) | | | | G3: 2 | | Reduction in objective binge frequency, %, mean: | G1: NR | G1: 13.6 (15.3) (P = NR)
| | (P = NS) | Past lowest BMI, mean (SD): | | | | Funding: | | G1: 70% | G2: NR | G2: 13.8 (14.2) (P = NR)
| | Completed and provided post assessment data, N: | 19.8 (2.2) | | | | Eli Lilly Canada Inc. | | G2: 80% | G3: NR | G3: 7.5 (9.0) (P = NR)
| | G1: 12 | Previous Dx of AN: | | | | | | G3: 87% | (P = NR) | Diff over time (P < 0.000)
| | G2: 14 | Total sample: 15.8% | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NR)
| | G3: 12 | G1: N = 1 | | | | | | | | Diff between groups in change over time (P = NR)
| | | G2: N = 3 | | | | | | Reduction in vomiting episodes, %, mean:
| | | G3: N = 2 | | | | | | G1: 37.4%
| | | Current mood disorders: | | | | | | G2: 79.2%
| | | Total sample: 13.2% | | | | | | G3: 82.4%
| | | G1: N = 2 | | | | | | Diff between groups (P < 0.05)
| | | G2: N = 0 | | | | | | G2 and G3 better than G1
| | | G3: N = 3 | | | | | Objective binges, mean (SD): | 4 Wks Post-tx:
| | | Lifetime mood disorder, N: | | | | | G1: 21.0 (12.2) | Objective binges, mean (SD):
| | | G1: 8 | | | | | G2: 33.6 (29.5) | G1: 10.0 (15.9) (P = NR)
| | | G2: 8 | | | | | G3: 29.6 (16.5) | G2: 7.4 (16.6) (P = NR)
| | | G3: 6 | | | | | (P = NS) | G3: 1.8 (3.3) (P = NR)
| | | Anxiety disorders: | | | | | | Diff between groups (P = NS)
| | | 10.5% | | | | | | Diff between G3 and G1 (P < 0.03)
| | | Substance use disorders: | | | | | | G3 better than G1
| | | 5.3% | | | | | | Diff between groups in change over time (P = NR)
| | | Personality disorders: | | | | | Subjective binges, mean (SD): | Subjective binges, mean (SD):
| | | Total sample: 18.4% | | | | | G1: 6.3 (9.6) | G1: 10.7 (13.3) (P = NR)
| | | Cluster A (G1 = 1; G2 = 0; G3 = 0) | | | | | G2: 3.2 (5.5) | G2: 1.9 (3.8) (P = NR)
| | | Cluster B (G1 = 1; G2 = 1; G3 = 1) | | | | | G3: 9.7 (14.3) | G3: 4.7 (6.2) (P = NR)
| | | Cluster 3 (G1 = 3; G2 = 0; G3 = 2) | | | | | (P = NS) | Diff between groups (P = 0.046)
| | | No diffs between groups on any characteristics. | | | | | | Diff between G2 and G1 (P < 0.02)
| | | | | | | | | G2 better than G1
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Vomit episodes, mean (SD): | Vomit episodes, mean (SD):
| | | | | | | | G1: 24.6 (20.4) | G1: 17.3 (27.2) (P = NR)
| | | | | | | | G2: 41.8 (34.4) | G2: 9.0 (16.8) (P = NR)
| | | | | | | | G3: 30.9 (29.7) | G3: 3.3 (4.5) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NS)
| | | | | | | | | Diff between G3 and G1 (P < 0.03)
| | | | | | | | | G3 better than G1
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE dietary restraint, mean (SD): | EDE dietary restraint, mean (SD):
| | | | | | | | G1: 3.8 (1.0) | G1: 2.3 (1.5) (P = NR)
| | | | | | | | G2: 3.1 (1.5) | G2: 1.6 (1.6) (P = NR)
| | | | | | | | G3: 3.7 (1.5) | G3: 1.6 (1.8) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE shape concern, mean (SD): | EDE shape concern, mean (SD):
| | | | | | | | G1: 4.1 (1.0) | G1: 2.8 (1.8) (P = NR)
| | | | | | | | G2: 3.0 (1.8) | G2: 2.3 (2.0) (P = NS)
| | | | | | | | G3: 3.7 (1.7) | G3: 2.3 (1.9) (P = NR)
| | | | | | | | (P = NS) | Diff over time (P < 0.0001), sig reductions in G1 and G3
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE wt concern mean (SD): | EDE wt concern, mean (SD):
| | | | | | | | G1: 3.4 (1.4) | G1: 2.1 (1.4) (P = NR)
| | | | | | | | G2: 2.6 (1.9) | G2: 1.8 (2.2) (P = NS)
| | | | | | | | G3: 3.3 (1.8) | G3: 1.8 (1.7) (P = NR)
| | | | | | | | (P = NS) | Diff over time (P < 0.0001), sig reductions in G1 and G3
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDI Drive for thinness: | EDI Drive for thinness:
| | | | | | | | G1: NR | G1(P = NR)
| | | | | | | | G2: NR | G2(P = NR)
| | | | | | | | G3: NR | G3(P = NR)
| | | | | | | | (P = 0.013) | Diff over time (P = NR)
| | | | | | | | G2 diff than G1 and G3 | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Abstinent (no binges or vomit episodes in 4 wks post tx), %, mean:
| | | | | | | | | G1: 17%
| | | | | | | | | G2: 43%
| | | | | | | | | G3: 25%
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Subthreshold ( < 2 binge or vomit episodes/wk in 4 wks posttx), %, mean:
| | | | | | | | | G1: 25%
| | | | | | | | | G2: 21%
| | | | | | | | | G3: 50%
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Threshold (2+ binge or vomit episodes per wk in the 4 wks post tx), %, mean:
| | | | | | | | | G1: 58%
| | | | | | | | | G2: 36%
| | | | | | | | | G3: 25%
| | | | | | | | | Diff between groups (P = NS)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | CBT (20 session, 16 wk) | Two-way ANCOVA (Site x Tx) using baseline values as covariate. | Score: | Objective binges, median (SD): | Abstinence, 34 wks, N (%): | BDI, mean (SD): | BDI, mean (SD):
Mitchell et al., 2002 | To investigate effect of meds management vs. IPT on abstinence rates in patients previously treated unsuccessfully with CBT (see Agras et al., 2000). | G1: IPT (N = 31) | G1: 28.0 (7.3) | Adult women who met DSM III-R criteria for BN with purging by self-induced vomiting at least 2 times per wk for 3 mo. | Those with active bulimic sx (purging) at the end of CBT tx randomized. | For binary outcomes, multiple logistic regression with site and tx as independent measures. | Fair | G1: 4.0 | G1: 5/31 (16.1) | G1: 9.9 (8.4) | G1: NR
Setting: | | G2: Antidepressant meds (fluoxetine; replaced with desipramine in those who did not achieve abstinence) (N = 31) | G2: 27.1 (6.3) | Exclusion: | G1: 20 sessions of IPT over 16 wks (developed by Klerman et al., 1984; modified by Fairburn, 1993), delivered by same therapist as previous CBT tx. | | Intent to treat: | G2: 5.0 | G2: 3/31 (9.7) | G2: 11.8 (10.0) | G2: NR
Outpatient, NY, NJ, Minnesota, USA | | Enrollment: | (P = NS) | Substance dependence in last 6 mo, hx of psychosis | G2: fluoxetine (60 mg/day; reduced if not well tolerated). For those who did not achieve abstinence at 60 mg over 8 wks, fluoxetine discontinued and desipramine initiated, beginning at a dose of 50 mg/day with subsequent increases to a max of 300 mg/day. | | Yes | (P = NR) | (P = NS) | (P = NR) | (P = NR)
Enrollment period: | | 847 contacted clinics; - 258 interviewed; - 194 enrolled in initial CBT tx study (NY:77; Minnesota: 79; NJ: 38); - 62 of those who remained symptomatic after CBT tx enrolled in current study (NY: 22; Minnesota: 28; NJ: 12) | Sex: | | Timeline: CBT: Wk 1–16; IPT/Meds: Wk 17 – 33. Post Assessment: wk 33 – 34; IPT discontinued at wk 33 and no further tx until FU. Med maintained at the same dosage until FU and was then discontinued. FU: wk 60 | | Blinding: | | Abstinence, 60 wks, N (%):
NR | | Completers (N = 37): | Female: 100% | | | | NA | | Of those abstinent at 34 wks, N (%):
| | G1: 21 | Race/ethnicity: | | | | Adverse events: | | G1: 2/5 (40)
| | G2: 16 | NR | | | | NR | | G2: 3/3 (100)
| | Drop outs (N = 25): | BMI, kg/m ^ 2 ^ , mean (SD): | | | | Funding: | | Of those not abstinent at wk 34, N (%):
| | G1: 10 | G1: 23.2 (3.7) | | | | McKnight Foundation | | G1: 3/26 (11.5)
| | G2: 15 | G2: 21.9 (2.5) | | | | | | G2: 0/28 (0.0)
| | Diff between sites (P = NS) | (P = NS) | | | | | | Relapse, 60 wks, N (%):
| | Diff between groups (P = NS) | Duration of bingeing, yrs, mean (SD): | | | | | | G1: 3/5 (60)
| | Completed FU (N = 33): | G1: 11.0 (6.7) | | | | | | G2: 0/3 (0.0)
| | G1: 18 | G2: 10.4 (7.1) | | | | | EDE restraint, mean (SD): | EDE restraint, mean (SD): | RSE, mean (SD): | RSE, mean (SD):
| | G2: 15 | (P = NS) | | | | | G1: 2.0 (1.3) | G1: NR | G1: 23.6 (7.5) | G1: NR
| | Drop out FU (N = 4): | Duration of purging, yrs, mean (SD): | | | | | G2: 2.6 (1.5) | G2: NR | G2: 23.7 (6.0) | G2: NR
| | G1: 3 | G1: 10.7 (6.7) | | | | | (P = NR) | (P = NR) | (P = NR) | (P = NR)
| | G2: 1 | G2: 8.9 (6.3) | | | | | EDE Wt Concerns, mean (SD): | EDE Wt Concerns, mean (SD):
| | | (P = NS) | | | | | G1: 2.5 (1.3) | G1: NR
| | | Hx of AN, %: | | | | | G2: 2.4 (1.5) | G2: NR
| | | G1: 29 | | | | | (P = NR) | (P = NR)
| | | G2: 36 | | | | | EDE Shape Concerns, mean (SD): | EDE Shape Concerns, mean (SD):
| | | (P = NS) | | | | | G1: 2.9 (1.4) | G1: NR
| | | Hx of depression, %: G1: 45 | | | | | G2: 2.8 (1.5) | G2: NR
| | | G2: 64 | | | | | (P = NR) | (P = NR)
| | | (P = NS) | | | | | EDE Eating Concerns, mean (SD): | EDE Eating Concerns, mean (SD):
| | | Current depression, %: | | | | | G1: 1.3 (0.9) | G1: NR
| | | G1: 26 | | | | | G2: 1.9 (1.4) | G2: NR
| | | G2: 26 | | | | | (P = NR) | (P = NR)
| | | (P = NS) | | | | | BES, mean (SD): | BES, mean (SD):
| | | Personality Disorder, %: G1: 42 | | | | | G1: 17.7 (9.9) | G1: NR
| | | G2: 54 | | | | | G2: 20.8 (10.4) | G2: NR
| | | (P = NS) | | | | | (P = NR) | (P = NR)
| | | Hx of substance abuse, %: | | | | | TFEQ - Restraint, mean (SD): | TFEQ - Restraint, mean (SD):
| | | G1: 13 | | | | | G1: 12.5 (4.1) | G1: NR
| | | G2: 16 | | | | | G2: 13.8 (4.4) | G2: NR
| | | (P = NS) | | | | | (P = NR) | (P = NR)
| | | | | | | | TFEQ - Disinhibition, mean (SD): | TFEQ - Disinhibition, mean (SD):
| | | | | | | | G1: 9.6 (3.2) | G1: NR
| | | | | | | | G2: 9.9 (3.4) | G2: NR
| | | | | | | | (P = NR) | (P = NR)
| | | | | | | | TFEQ - Hunger, mean (SD): | TFEQ - Hunger, mean (SD):
| | | | | | | | G1: 6.8 (3.5) | G1: NR
| | | | | | | | G2: 7.7 (3.3) | G2: NR
| | | | | | | | (P = NR) | (P = NR)
| | | | | | | | Bulimic Thoughts Questionnaire, mean (SD): | Bulimic Thoughts Questionnaire, mean (SD):
| | | | | | | | G1: 49.1 (16.8) | G1: NR
| | | | | | | | G2: 50.0 (17.4) | G2: NR
| | | | | | | | (P = NR) | (P = NR)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD) (range): | Inclusion: | Baseline: interview, exam, assessment instruments. Instructed to self-monitored tx and return to the clinic in 2 wk to reassess admission criteria. | Baseline comparisons - one way ANOVA | Score: | Episodes of vomiting, mean (SD): | At Wk 4 (after 2 wks of active tx): | HAM-D, mean (SD): | At Endpoint:
Mitchell et al., 2001 | To examine the singular and combined effects of fluoxetine and a self-help manual on suppressing bulimic behaviors in BN. | G1: Placebo only (N = 22) | Total sample: 26.6 (7.1) (18–46) | Female, at least 18 yrs old, at least 85% of IBW, DSM III-R criteria for BN and binge eating/vomiting 3 times per wk for last 6 mos, | Randomized into single blind for 2 wks. Participants who reported < 75% improvement in the number of vomiting episodes were then randomized. | Chi squares and Fisher exact test | Fair | G1: 11.77 (6.67) | Vomiting, % decrease from baseline, mean (SD): | G1: 10.91 (5.89) | HAM-D:
Setting: | | G2: Fluoxetine Only (N = 26) | G1: 23.8 (6.1) | Exclusion: | Patients seen wkly for 4 wks and then every other wk for 12 wks (by RA) and every other wk for 12 wks (by investigator). | Two-way ANOVA | Intent to treat: | G2: 16.81 (27.72) | G1: 21.8 (48.1) (P = NR) | G2: 8.85 (6.83) | G1: NR
Outpatient University of Minnesota Hospital eating disorders program, USA | | G3: Placebo and Self-Help Manual (N = 22) | G2: 26.6 (7.1) | Currently receiving pharmacotherapy or psychotherapy; medical condition that would preclude safe outpt tx, hx of hypersensitivity to fluoxetine, prior exposure to fluoxetine in a total amt > 140 mg or within preceding 5 wks before entering study. | Meds: 60 mg/day fluoxetine for 16 wks. | Cochran-Mantel-Haenszel for response rates | Yes | G3: 13.86 (10.81) | G2: 46.1 (39.5) (P = NR) | G3: 10.14 (7.01) | G2: NR
Enrollment period: | | G4: Fluoxetine and Self-Help Manual (N = 21) | G3: 26.8 (6.9) | | Manual: instructed to follow daily assignments. 14 readings/homework assignments equaling 1 hr each night: normalizing eating, behavioral strategies, cognitive restructuring, body image, relapse prevention. | | Blinding: | G4: 12.43 (6.92) | G3: 31.5 (66.4) (P = NR) | G4: 8.10 (6.56) | G3: NR
NR | | Enrollment: | G4: 29.3 (7.8) | | | | First 2 wks: Single | (P = NS) | G4: 66.7 (28.9) (P = NR) | (P = NS) | G4: NR
| | N = 91 | (P = NS) | | | | Remainder: NR | Days of vomiting, mean (SD): | Diff between groups (P = 0.012) | | Diff between groups (P = NR)
| | Endpoint (at least 1 post-randomization measurement), N: | Sex: | | | | Adverse events: | G1: 5.59 (1.65) | G2+G4 better than G1+G3 | | Diff between groups in change over time (P = NS)
| | Total sample: 89 | Female: 100% | | | | NR | G2: 5.65 (1.60) | Diff between groups (P = 0.033)
| | G1: 21 | Race/ethnicity: | | | | Funding: | G3: 6.09 (1.66) | G3+G4 better than G1+G2
| | G2: 26 | White, N (%): | | | | Dista Pharmaceuticals | G4: 6.05 (1.36) | At Endpoint:
| | G3: 22 | G1: 21 (95.5) | | | | NIMH | (P = NS) | Vomiting, % decrease from baseline, mean (SD):
| | G4: 20 | G2: 25 (100) | | | | McKnight Foundation | | G1: 22.8 (56.1) (P = NR)
| | Wk 4 (evaluable data at wk 4), N: | G3: 22 (100) | | | | | | G2: 52.8 (50.7) (P = NR)
| | Total sample: 83 | G4: 20 (95.2) | | | | | | G3: 50.2 (55.0) (P = NR)
| | G1: 18 | (P = NS) | | | | | | G4: 66.7 (31.2) (P = NR)
| | G2: 25 | Height, cm, mean (SD): | | | | | | Diff between groups (P = 0.043)
| | G3: 21 | G1: 165.1 (6.9) | | | | | | G2+G4 better than G1+G3
| | G4: 19 | G2: 162.6 (7.0) | | | | | Episodes of binge eating, mean (SD): | At Wk 4 (after 2 wks of active tx): | CGI Severity, mean (SD): | CGI Improvement:
| | | G3: 164.3 (5.7) | | | | | G1: 9.45 (5.34) | Binge eating, % decrease from baseline, mean (SD): | G1: 4.82 (0.59) | G1: NR
| | | G4: 162.7 (7.0) | | | | | G2: 11.58 (6.74) | G1: 26.9 (62.1) (P = NR) | G2: 4.69 (0.62) | G2: NR
| | | (P = NS) | | | | | G3: 11.91 (10.70) | G2: 43.4 (36.2) (P = NR) | G3: 4.82 (0.66) | G3: NR
| | | Wt, kg, mean (SD): | | | | | G4: 11.29 (5.87) | G3: 35.4 (66.0) (P = NR) | G4: 5.00 (0.77) | G4: NR
| | | G1: 60.7 (7.8) | | | | | (P = NS) | G4: 61.6 (31.5) (P = NR) | (P = NS) | Diff between groups (P = 0.029)
| | | G2: 59.5 (13.9) | | | | | Days of binge eating, mean (SD): | Diff between groups (P = NS) | | G2+G4 better than G1+G3
| | | G3: 61.2 (10.5) | | | | | G1: 5.45 (1.68) | At Endpoint:
| | | G4: 56.4 (6.8) | | | | | G2: 5.96 (1.40) | Binge eating, % decrease from baseline, mean (SD):
| | | (P = NS) | | | | | G3: 5.73 (1.78) | G1: 32.4 (66.7) (P = NR)
| | | Smoking, Yes, N (%): | | | | | G4: 6.10 (1.37) | G2: 50.3 (52.6) (P = NR)
| | | G1: 11 (50) | | | | | (P = NS) | G3: 59.7 (39.6) (P = NR)
| | | G2: 8 (30.8) | | | | | | G4: 66.8 (29.9) (P = NR)
| | | G3: 7 (31.8) | | | | | | Diff between groups (P = NS)
| | | G4: 3 (14.3) | | | | | Days of fasting, mean (SD): | At Endpoint: | | Patient's Global Improvement Scales (P GI):
| | | (P = NS) | | | | | G1: 1.18 (2.20) | Days of fasting, mean (SD): | | G1: NR
| | | Alcohol Use, Yes, N (%): | | | | | G2: 0.54 (1.07) | G1: NR | | G2: NR
| | | G1: 12 (54.5) | | | | | G3: 0.59 (1.74) | G2: NR | | G3: NR
| | | G2: 15 (57.7) | | | | | G4: 0.48 (1.03) | G3: NR | | G4: NR
| | | G3: 13 (59.1) | | | | | (P = NS) | G4: NR | | Diff between groups (P = 0.036)
| | | G4: 10 (47.6) | | | | | | (P = NR) | | G2+G4 better than G1+G3
| | | (P = NS) | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDI total score, mean (SD): | At Endpoint:
| | | | | | | | G1: 72.11 (14.59) | EDI total score, mean (SD):
| | | | | | | | G2: 66.79 (16.21) | G1: NR
| | | | | | | | G3: 68.74 (18.48) | G2: NR
| | | | | | | | G4: 58.11 (15.14) | G3: NR
| | | | | | | | (P = NS) | G4: NR
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Abstinence rates:
| | | | | | | | | G1: NR
| | | | | | | | | G2: 16%
| | | | | | | | | G3: 24%
| | | | | | | | | G4: 26%
| | | | | | | | | (P = NS)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Physicians were internists with limited experience in ED. Nurses had no specialized training in ED. Physicians and nurses received brief ( < 2 hr) training in BN, guided self-help, and fluoxetine tx for BN. | ANCOVA. Proportional odds polytomous logistic regression | Score: | EDE interview, mean (SD): | EDE interview, mean (SD): | BDI, mean (SD): | BDI, mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD):
Walsh et al., 2004 | To evaluate relative and combined benefits of fluoxetine and guided self-help for BN in a primary care setting. | G1: Fluoxetine and guided self-help (N = 24) | 30.6 (7.8) | Modified DSM IV criteria: included “moderately” large amounts of food during binges, and binge at least once per wk for 3 mos. Woman, age 18–60, BMI > 17.5 | - Initial visit - met with physician for hx, exam, meds. patient returned 2 wks later for evaluation. All patients scheduled for 4 additional 15 minutes visit at moly intervals.; - Med conditions -60 mg /day; - Guided self help - received self-help book and instructions during initial visit. In addition to moly physician visits, met with nurse for 6 – 8 30 minutes sessions. First 4 were wkly during the first mo; 5th - 6th moly; 7 – 8th optional in the 3rd or 4th mo. Focused on encouraging patients to progress through self-help manual. | | Good | Objective bulimic episodes/mo: | Objective bulimic episodes/mo: | G1: 19.74 (11.85) | G1: 12.52 (11.77) (P = NR) | G1: 21.79 (3.40) | G1: 21.68 (3.47) (P = NR)
Setting: | | G2: Placebo and guided self help (N = 25) | Duration of BN, yrs, mean (SD): | Exclusion: | | | Intent to treat: | G1: 27.42 (23.88) | G1: 16.83 (24.65) (P = NR) | G2: 19.56 (11.64) | G2: 17.24 (11.74) (P = NR) | G2: 22.78 (4.33) | G2: 22.61 (4.49) (P = NR)
Primary care clinics, Connecticut and Manhattan, NY, USA | | G3: Fluoxetine only (N = 20) | 12.0 (7.9) | Pregnant, substantial medical illness, psychotropic drug use, meds known to influence shape or wt, previously received course of 60 mg/day of fluoxetine for at least 4 wks, received CBT, adverse reaction to fluoxetine, currently in other psychological /psychiatric tx, substantial alcohol or substance abuse or dependence in the last 6 mo, other serious psychiatric dx requiring immediate tx or actively suicidal. | | | Yes | G2: 27.80 (25.64) | G2: 26.92 (26.79) (P = NR) | G3: 18.40 (9.65) | G3: 12.25 (10.38) (P = NR) | G3: 24.29 (5.49) | G3: 24.58 (6.46) (P = NR)
Enrollment period: | | G4: (Placebo only; N = 22) | Met full DSM IV criteria for BN, N (%): | | | | Blinding: | G3: 24.20 (22.60) | G3: 17.25 (23.93) (P = NR) | G4: 18.41 (9.15) | G4: 15.95 (11.23) (P = NR) | G4: 24.00 (3.72) | G4: 23.89 (4.08) (P = NR)
March 1998 – October 2001 | | Enrollment: | 76 (83.5) | | | | NR | G4: 23.95 (15.57) | G4: 20.09 (19.64) (P = NR) | (P = NS) | Diff between groups G1+G2 vs G3+G4 (P = NS) | (P = NS) | Diff between groups G1+ G2 vs G3+G4 (P = NS)
| | - 227 contacted clinic and met phone screening; - 101 chose to come for in person screening; - 91 met criteria and were randomized; - Completed tx, N (%): 28 (30.8%); G1: 11; G2: 3; G3: 6; G4: 8.; - Diff in attrition; - fluoxetine (G1 + G3) vs placebo (G2 + G4) (P = 0.02); G1/G3 had less attrition); - Guided self-help (G1 + G2) vs pills only (G3 + G4) (P = NS) | Received previous tx, N (%): | | | | Adverse events: | (P = NS) | Diff between groups G1+G2 vs G3+G4 (P = NS) | | Diff between groups G1+G3 better than G2+G4 (P = 0.01) | | Diff between groups G1+ G3 vs G2+G4 (P = NS)
| | | 28 (32.2) | | | | NR | | Diff between groups G1+G3 better than G2+G4 (P = 0.03) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | Sex: | | | | Funding: | | Diff between groups in change over time (P = NR)
| | | Female: 100% | | | | NIDDK, Welcome Trust, Eli Lilly and Company | Subjective Bulimic Episodes/mo: | Subjective Bulimic Episodes/mo: | SCL-53, mean (SD): | SCL-53, mean (SD):
| | | Race/ethnicity, N (%): | | | | | G1: 17.58 (25.19) | G1: 14.25 (23.54) (P = NR) | G1: 1.36 (0.80) | G1: 1.03 (0.88) (P = NR)
| | | Caucasian: 84 (92.3) | | | | | G2: 15.84 (22.37) | G2: 13.88 (20.79) (P = NR) | G2: 1.49 (0.93) | G2: 1.36 (0.88) (P = NR)
| | | Hispanic: 5 (5.5) | | | | | G3: 16.25 (16.06) | G3: 3.70 (7.80) (P = NR) | G3: 1.26 (0.77) | G3: 0.95 (0.77) (P = NR)
| | | Asian: 1 (1.1) | | | | | G4: 15.09 (18.85) | G4: 6.68 (12.73) (P = NR) | G4: 1.20 (0.69) | G4: 1.22 (0.85) (P = NR)
| | | African American: 1 (1.1) | | | | | (P = NS) | Diff between groups G1+G2 worse than G3+G4 (P = 0.01) | (P = NS) | Diff between groups G1+G2 vs G3+G4 (P = NS)
| | | Comorbidty, N (%): | | | | | | Diff between groups G1+G3 vs G2+G4 (P = NS) | | Diff between groups G1+G3 better than G2+G4 (P = 0.02)
| | | MDD: 30 (33.3) | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | Past MDD: 28 (31.1) | | | | | Days of vomiting/mo: | Days of vomiting/mo:
| | | | | | | | G1: 20.29 (9.62) | G1: 11.83 (11.86) (P = NR)
| | | | | | | | G2: 20.12 (9.18) | G2: 20.00 (9.63) (P = NR)
| | | | | | | | G3: 18.80 (9.36) | G3: 11.55 (10.60) (P = NR)
| | | | | | | | G4: 17.55 (9.01) | G4: 13.68 (10.63) (P = NR)
| | | | | | | | (P = NS) | Diff between groups G1+G2 vs G3+G4 (P = NS)
| | | | | | | | | Diff between groups G1+G3 better than G2+G4 (P = 0.004)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Episodes of vomiting/mo: | Episodes of vomiting/mo:
| | | | | | | | G1: 38.04 (25.08) | G1: 21.04 (27.08) (P = NR)
| | | | | | | | G2: 44.16 (56.14) | G2: 46.12 (56.75) (P = NR)
| | | | | | | | G3: 34.30 (29.34) | G3: 19.85 (25.80) (P = NR)
| | | | | | | | G4: 26.32 (18.09) | G4: 21.32 (20.89) (P = NR)
| | | | | | | | (P = NS) | Diff between groups G1+G2 vs G3+G4 (P = NS)
| | | | | | | | | Diff between groups G1+G3 better than G2+G4 (P = 0.002)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Episodes of laxative use/mo: | Episodes of laxative use/mo:
| | | | | | | | G1: 2.54 (6.67) | G1: 2.25 (6.60) (P = NR)
| | | | | | | | G2: 3.64 (8.15) | G2: 2.36 (6.42) (P = NR)
| | | | | | | | G3 (4.70 (10.20) | G3: 3.90 (9.48) (P = NR)
| | | | | | | | G4: 3.45 (7.66) | G4: 3.05 (6.55) (P = NR)
| | | | | | | | (P = NS) | Diff between groups G1+G2 vs G3+G4 (P = NS)
| | | | | | | | | Diff between groups G1+G3 vs G2+G4 (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Restraint rating for past mo: | Restraint rating for past mo:
| | | | | | | | G1: 5.00 (2.00) | G1: 3.67 (2.62) (P = NR)
| | | | | | | | G2: 5.16 (1.99) | G2: 4.92 (2.08) (P = NR)
| | | | | | | | G3: 5.20 (1.67) | G3: 3.90 (2.65) (P = NR)
| | | | | | | | G4: 5.24 (1.58) | G4: 4.19 (2.75) (P = NR)
| | | | | | | | (P = NS) | Diff between groups G1+G2 vs G3+G4 (P = NS)
| | | | | | | | | Diff between groups G1+G3 better than G2+G4 (P = 0.03)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE questionnaire, mean (SD): | EDE questionnaire, mean (SD)
| | | | | | | | Objective bulimic episodes /mo: | Objective bulimic episodes /mo:
| | | | | | | | G1: 20.70 (15.46) | G1: 10.13 (13.14) (P = NR)
| | | | | | | | G2: 17.92 (16.19) | G2: 13.88 (15.97) (P = NR)
| | | | | | | | G3: 16.65 (12.82) | G3: 8.10 (9.09) (P = NR)
| | | | | | | | G4: 15.48 (10.78) | G4: 9.91 (10.03) (P = NR)
| | | | | | | | (P = NS) | Diff between groups G1+G2 vs G3+G4 (P = NS)
| | | | | | | | | Diff between groups G1+G3 vs G2+G4 (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Subjective Bulimic Episodes/mo: | Subjective Bulimic Episodes/mo:
| | | | | | | | G1: 10.19 (8.84) | G1: 9.00 (20.85) (P = NR)
| | | | | | | | G2: 10.45 (10.32) | G2: 7.91 (9.29) (P = NR)
| | | | | | | | G3: 8.95 (9.23) | G3: 3.11 (5.92) (P = NR)
| | | | | | | | G4: 7.45 (8.61) | G4: 4.14 (5.38) (P = NR)
| | | | | | | | (P = NS) | Diff between groups G1+G2 vs G3+ G4 (P = NS)
| | | | | | | | | Diff between groups G1+G3 vs G2+ G4 (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Days of vomiting/mo: | Days of vomiting/mo:
| | | | | | | | G1: 20.74 (9.12) | G1: 10.33 (10.93) (P = NR)
| | | | | | | | G2: 19.32 (9.42) | G2: 17.20 (10.98) (P = NR)
| | | | | | | | G3: 18.30 (10.19) | G3: 11.15 (10.63) (P = NR)
| | | | | | | | G4: 17.32 (8.95) | G4: 12.45 (10.00) (P = NR)
| | | | | | | | (P = NS) | Diff between groups G1+G2 vs G3+G4 (P = NS)
| | | | | | | | | Diff between groups G1+G3 better than G2+G4 (P = 0.04)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Days of laxative use/mo: | Days of laxative use/mo:
| | | | | | | | G1: 2.70 (6.55) | G1: 2.21 (6.47) (P = NR)
| | | | | | | | G2: 4.32 (8.78) | G2: 2.88 (7.32) (P = NR)
| | | | | | | | G3: 4.89 (10.11) | G3: 2.70 (7.60) (P = NR)
| | | | | | | | G4: 3.77 (8.12) | G4: 2.95 (6.60) (P = NR)
| | | | | | | | (P = NS) | Diff between groups G1+G2 vs G3+G4 (P = NS)
| | | | | | | | | Diff between groups G1+G3 vs G2+G4 (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Remission (absence of bingeing, vomiting, or laxative use for 1 mo) (N, %):
| | | | | | | | | Diff between groups G1+ G2 (6, 12.2%) vs G3+G4
| | | | | | | | | (4, 9.5%) (P = NS)
| | | | | | | | | Diff between groups G1+G3 (7, 15.9%) vs G2+G4
| | | | | | | | | (3, 6.4%) (P = NS)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Combination of therapy and meds or placebo, except for the ‘Meds only’ group. Both CBT and supportive therapy designed to include 20 sessions over 16 wks. ‘Meds only’ group expected to attend 16 sessions over 16 wks. | Logistic regression analyses for outcomes of remission and completion of tx and regression for termination frequency. Survival analyses comparing variables among the tx's. Repeated measures ANOVA's. | Score: | | Logistic Regression Analyses: | NR | Helping Relationship Questionnaire (Therapeutic Alliance), mean (SD): | NR | NR
Wilson et al., 1999 | Examine effect of therapeutic alliance, predictive factors and time course of change on psychological and pharmacological tx of BN. | G1: CBT + Meds (N = 23) | G1: 26.1 (5.7) | Meet DSM III-R criteria for BN for at least 1 yr; had to use self-induced vomiting as compensatory mechanism; Female between ages 18–45; wt between 80–120% of IBW | CBT: based on manual (Wilson, 1989) derived from Fairburn et al. CBT included: self-monitoring, triggers, cognitive restructuring, coping strategies, problem solving, and dysfunctional cognitions. | | Good | | Likelihood of remission, predictor variable, odds ratio [95% CI]: | | *error in paper
Companion article: | | G2: CBT + Placebo (N = 25) | G2: 25.8 (4.4) | Exclusion: | Supportive therapy: modified version of a manual-based approach (Fairburn et al.); aspects of tx that were similar to CBT eliminated. | | Intent to treat: | | CBT (G1+G3), OR = 4.81 [1.32–17.53] (P = 0.02), CBT increased likelihood of remission | | G1: 23.58 (4.56)
Walsh et al., 1997 | | G3: Supportive therapy + Meds (N = 22) | G3: 28.0 (5.3) | Medically ill; possible cardiac conduction disease; pregnant; abused alcohol or drugs in past yr; appeared acutely suicidal; prior adverse reaction to desipramine or fluoxetine | Meds: desipramine (up to 300 mg/day avg dose 188 mg/day) first for 8 wks. If binge frequency not reduced by at least 75% or if intolerable side effects occurred, desipramine tapered and discontinued over next 2 wks and given fluoxetine (up to 60 mg/day avg dose 55 mg/day). | | Yes | | HRQ, OR = NR (P = NR), higher therapeutic alliance increased likelihood of remission | | G2: 19.74 (8.60)
Setting: | | G4: Supportive therapy + placebo (N = 22) | G4: 26.9 (4.3) | | Placebo: same rules followed (8 wks of tx and if no 75% reduction in binge freq or side effects, tapering and discontinuation and switch to fluoxetine placebo). | | Blinding: | | Predictors of Worse Outcome (end of tx binge and vomit frequencies): | | G3: 18.76 (7.81)
Outpatient New York State Psychiatric Unit, Columbia University, USA | | G5: Meds only (N = 28) | G5: 24.3 (4.5) | | In the first wk of tx, dose of desipramine increased to 200 mg/day and if tolerated, continued for 3 wks. If needed, dose increased to 300 mg/day. Fluoxetine started at 60 mg/day with the option to lower the dose to minimize side effects. | | Double, within groups receiving psychological tx | | Higher baseline binge and vomit frequencies (P = 0.0001) | | G4: 20.55 (7.94)
Enrollment period: | | Enrollment: | (P = NS) | | | | Adverse events: | | CBT assignment (P = 0.02) | | G5: 15.09 (7.79)
NR | | - Recruitment through advertisements in media; - Individuals screened on telephone using EDE and SCID (DSM III-R); - 209 met with psychiatrist who confirmed dx and did physical; - Eligible participants entered single-blind washout phase for 7–10 days; - 120 who continued to meet criteria randomly assigned to one of the groups | Sex: | | | | NR | | Positive hx of AN (P = 0.05) | | Diff between groups (P = NS)
| | | Female: 100% | | | | Funding: | | Positive hx of substance abuse (P = 0.04) | | Diff between groups in change over time
| | | Race/ethnicity, %: | | | | NIMH; Eli Lilly; Marion Merrell Dow | | | | G1 vs. G2 (P = NR)
| | | White: 83% | | | | | | | | G3 vs. G4 (P = 0.03)
| | | African American: 6% | | | | | | | | *text states higher therapeutic alliance (higher HRQ) with meds vs. placebo within supportive tx and higher alliance with placebo vs. meds within CBT.
| | | Hispanic: 6% | | | | | Binges/wk, mean (SD): | Survival Analyses, hazard ratio [95% CI]:
| | | Asian: 5% | | | | | G1: 7.29 (4.8) | Binge eating:
| | | (P = NS) | | | | | G2: 7.22 (4.0) | G1+G2 better than G3+G4, HR = 1.88 [1.08–3.26], especially if baseline BSQ or eating restraint were low
| | | Duration of BN, yrs, mean (SD): | | | | | G3: 7.92 (5.6) | - If BSQ < 140, HR = 3.54 [1.57–8.00]; - If BSQ > 140, HR = 1.04 [0.52–2.10]; - Low EDE restraint, HR = 3.37 [1.45–7.81]; - High EDE restraint, HR = 1.12 [0.55–2.28]
| | | G1: 7.26 (5.8) | | | | | G4: 6.18 (3.6)
| | | G2: 8.0 (4.0) | | | | | G5: 8.32 (7.5)
| | | G3: 9.55 (5.3) | | | | | (P = NS)
| | | G4: 7.55 (3.7) | | | | | | Repeated Measures ANOVA:
| | | G5: 7.36 (4.3) | | | | | | Binge eating, overall:
| | | (P = NS) | | | | | | Diff between groups G1+G2 better than G3+G4 (P = 0.003)
| | | Current major depression, %: | | | | | | Diff between groups in change over time, quadratic effect: G1+G2 better than G3+G4 in initial binge reduction
| | | G1: 17% | | | | | | (P = 0.05); G1+G3 vs. G2+G4 (P = NS)
| | | G2: 24% | | | | | | Binge eating (wks 1–3):
| | | G3: 23% | | | | | | Diff between groups (P = NS)
| | | G4: 9% | | | | | | Diff between groups in change over time, linear effects: G1+G2 better than G3+G4 (P = 0.001)
| | | G5: 29% | | | | | | G1+G3 vs. G2+G4 (P = NS)
| | | (P = NS) | | | | | | Binge eating (wks 4–16):
| | | Past AN, %: | | | | | | Diff between groups (P = NR)
| | | G1: 17% | | | | | | Diff between groups in change over time, cubic effect: G1+G3 better than G2+G4 (P = 0.03)
| | | G2: 36% | | | | | Vomiting episodes/wk, mean (SD): | Survival Analyses, hazard ratio [95% CI]:
| | | G3: 32% | | | | | G1: 10.8 (13) | Vomiting:
| | | G4: 27% | | | | | G2: 10.8 (12) | G1+G2 better than G3+G4, HR = 4.73 [2.21–10.10], especially if baseline BDI was high
| | | G5: 32% | | | | | G3: 10.6 (9) | - If BDI < 20, HR = 2.91 [1.25–6.79]; - If BDI > 20, HR = 29.34 [4.72–182.15]
| | | (P = NS) | | | | | G4: 11.9 (13) | G1+G3 better than G2+G4, HR = 2.01 [1.04–3.89], especially if baseline BDI was high
| | | | | | | | G5: 10.5 (11) | - BDI < 20 subgroup, HR = 1.22 [0.55–2.70]; - BDI > 20 subgroup, HR = 6.79 [2.90–15.88]
| | | | | | | | (P = NS) | Repeated Measures ANOVA:
| | | | | | | | | Vomiting, overall:
| | | | | | | | | Diff between groups:
| | | | | | | | | G1+G2 better than G3+G4 (P = 0.002)
| | | | | | | | | G1+G3 better than G2+G4 (P = 0.04)
| | | | | | | | | Vomiting (wks 1–3):
| | | | | | | | | Diff between groups G1+G3 better than G2+G4 Diff between groups (P = 0.04)
| | | | | | | | | Vomiting (wks 4–16):
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time, quadratic effect: G1+G3 better than G2+G4 (P = 0.03)
| | | | | | | | | For CBT, early responders remained superior to others over the course of tx.
| | | | | | | | | For supportive therapy, improvement in early responders deteriorated.
| | | | | | | | | Time to remission:
| | | | | | | | | G1+G3 vs. G2+G4 (P = NS)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Combination of therapy and meds or placebo, except for the ‘Meds only’ group. Both CBT and supportive therapy designed to include 20 sessions over 16 wks. Those receiving ‘meds only’ expected to attend 16 sessions over 16 wks. | ANOVA for continuous variables and logistic regressions for categorical variables to examine diffs between pre and post tx levels. Odds ratio values were tested with chi square tests. | Score: | Binges/wk, mean (SD): | Binges/ wk, mean (SD): | BDI, mean (SD): | BDI, mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD):
Walsh et al., 1997 | Compare supportive therapy with CBT and see if meds tx (desipramine, or desipramine followed by fluoxetine in meds non-responders) adds to tx efficacy for BN. | G1: CBT + Meds (N = 23) | G1: 26.1 (5.7) | DSM III-R criteria for BN for at least 1 yr; had to use self-induced vomiting as compensatory mechanism; Female: between ages 18–45; wt between 80–120% of IBW | CBT based on a manual (Wilson, 1989) derived from Fairburn et al., Components of CBT included: self-monitoring, triggers, cognitive restructuring, coping strategies, problem solving, and dysfunctional cognitions. | | Good | G1: 7.29 (4.8) | G1: 0.95 (1.6) (P < 0.05) | G1: 10.9 (6) | G1: 4.4 (5) (P < 0.05) | G1: 21.6 (2.2) | G1: 21.5 (2.1) (P = NR)
Companion article: | | G2: CBT + Placebo (N = 25) | G2: 25.8 (4.4) | Exclusion: | Supportive therapy: modified version of a manual-based approach (Fairburn et al.); aspects of the tx that were similar to CBT eliminated. | | Intent to treat: | G2: 7.22 (4.0) | G2: 2.56 (3.3) (P < 0.05) | G2: 11.7 (10) | G2: 6.8 (7) (P < 0.05) | G2: 22.1 (2.1) | G2: 22.6 (2.3) (P < 0.05)
Wilson et al., 1999 | | G3: Supportive therapy + Meds (N = 22) | G3: 28.0 (5.3) | Medically ill; possible cardiac conduction disease; pregnant; abused alcohol or drugs in past yr; appeared acutely suicidal; prior adverse reaction to desipramine or fluoxetine | Participants receiving meds received desipramine (up to 300 mg/day avg dose 188 mg/day) first for 8 wks. If binge frequency not reduced by ≥ 75% or if intolerable side effects occurred, the desipramine was tapered and discontinued over the next 2 wks and patients were then given fluoxetine (up to 60 mg/day avg dose 55 mg/day). The same rules were followed for those receiving placebo (8 wks of tx and if no 75% reduction in binge freq or side effects, tapering and discontinuation and switch to fluoxetine placebo). | | Yes | G3: 7.92 (5.6) | G3: 3.57 (3.1) (P < 0.05) | G3: 15.9 (12) | G3: 6.7 (7) (P < 0.05) | G3: 21.7 (2.3) | G3: 21.2 (2.5) (P < 0.05)
Setting: | | G4: Supportive therapy + placebo (N = 22) | G4: 26.9 (4.3) | | In the first wk of tx, the dose of desipramine was increased to 200 mg/day and if tolerated, this was continued for 3 wks. If needed, the dose was increased to 300 mg/day. Fluoxetine was started at 60 mg/day with the option to lower the dose to minimize side effects. | | Blinding: | G4: 6.18 (3.6) | G4: 3.32 (4.0) (P < 0.05) | G4: 14.3 (9) | G4: 10.2 (11) (P < 0.05) | G4: 21.7 (2.2) | G4: 22.1 (2.2) (P = NR)
Outpatient New York State Psychiatric Unit, Columbia University, USA | | G5: Meds only (N = 28) | G5: 24.3 (4.5) | | | | Double, within groups receiving psychological tx | G5: 8.32 (7.5) | G5: 2.59 (3.5) (P < 0.05) | G5: 14.5 (8) | G5: 8.2 (9) (P < 0.05) | G5: 22.3 (2.1) | G5: 21.7 (2.3) (P < 0.05)
Enrollment period: | | Enrollment: | (P = NS) | | | | Adverse events: | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR)
NR | | - Recruitment through advertisements in media; - Individuals screened on telephone using EDE and SCID (DSM III-R); - 209 individuals met with psychiatrist who confirmed dx and did physical; - Eligible participants entered single-blind washout phase for 7–10 days; - 120 who continued to meet criteria were randomly assigned to one of the groups | Sex: | | | | NR | | Diff between groups in change over time | | Diff between groups in change over time | | Diff between groups in change over time
| | Drop outs: | Female: 100% | | | | Funding: | | G1+G2 better than G3+G4 (P = 0.0005) | | G1+G2 vs. G3+G4 (P = NS) | | G1+G2 worse than G3+G4 (P = 0.02)
| | Overall: 34% | Race/ethnicity, %: | | | | NIMH; Eli Lilly; Marion Merrell Dow | | G1+G3 better than G2+G4 (P = 0.05) | | G1+G3 better than G2+G4 | | G1+G3 better than G2+G4 (P = 0.005)
| | Meds only group: 43% | White: 83% | | | | | | G1 better than G5 (P = 0.04) | | (P = 0.04) | | G1 worse than G5 (P = 0.01)
| | Psychotherapy groups: 32% (P = NS) | African American: 6% | | | | | | G3 vs. G5 (P = NS) | | G1 vs. G5 (P = NS) | | G3 vs. G5 (P = NS)
| | | Hispanic: 6% | | | | | | | | G3 vs. G5 (P = NS)
| | | Asian: 5% | | | | | Vomiting episodes/wk, mean (SD): | Vomiting episodes/wk, mean (SD): | SCL-90 Global Symptom index, mean (SD): | SCL-90 Global Symptom index, mean (SD): | Wt (lb), mean (SD): | Wt (lb), mean (SD):
| | | (P = NS) | | | | | G1: 10.8 (13) | G1: 1.1 (2) (P < 0.05) | G1: 1.83 (0.6) | G1: 1.39 (0.4) (P < 0.05) | G1: 126 (15) | G1: 125 (15) (P = NR)
| | | Duration of BN, yrs, mean (SD): | | | | | G2: 10.8 (12) | G2: 5.6 (15) (P < 0.05) | G2: 1.69 (0.5) | G2: 1.47 (0.5) (P < 0.05) | G2: 130 (11) | G2: 133 (11) (P < 0.05)
| | | G1: 7.26 (5.8) | | | | | G3: 10.6 (9) | G3: 5.5 (5) (P < 0.05) | G3: 1.88 (0.6) | G3: 1.51 (0.5) (P < 0.05) | G3: 133 (17) | G3: 131 (18) (P < 0.05)
| | | G2: 8.0 (4.0) | | | | | G4: 11.9 (13) | G4: 7.5 (10) (P < 0.05) | G4: 1.66 (0.3) | G4: 1.51 (0.5) (P = NR) | G4: 130 (15) | G4: 133 (13) (P = NR)
| | | G3: 9.55 (5.3) | | | | | G5: 10.5 (11) | G5: 3.7 (5) (P < 0.05) | G5: 1.73 (0.4) | G5: 1.41 (0.4) (P < 0.05) | G5: 131 (17) | G5: 128 (16) (P < 0.05)
| | | G4: 7.55 (3.7) | | | | | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR) | (P = NS) | G1+G2 (+1.13 lb) worse than G3+G4
| | | G5: 7.36 (4.3) | | | | | | Diff between groups in change over time | | Diff between groups in change over time | | (-1.29 lb) (P = 0.03)
| | | (P = NS) | | | | | | G1+G2 better than G3+G4 (P = 0.0002) | | G1+G2 vs. G3+G4 (P = NS) | | G1+G3 (-1.54 lb) better than G2+G4 (+1.49 lb) (P = 0.007)
| | | Current major depression, %: | | | | | | G1+G3 vs. G2+G4 (P = NS) | | G1+G3 vs. G2+G4 (P = NS) | | G1 worse than G5 (P = 0.02)
| | | G1: 17% | | | | | | G1 better than G5 (P = 0.01) | | G1 vs. G5 (P = NS) | | G3 vs. G5 (P = NS)
| | | G2: 24% | | | | | | G3 vs. G5 (P = NS) | | G3 vs. G5 (P = NS)
| | | G3: 23% | | | | | EAT, mean (SD): | EAT, mean (SD): | SCL-90 Depression Index, mean (SD): | SCL-90 Depression Index, mean (SD):
| | | G4: 9% | | | | | G1: 45.0 (13) | G1: 19.1 (12) (P < 0.05) | G1: 2.16 (0.8) | G1: 1.47 (0.5) (P < 0.05)
| | | G5: 29% | | | | | G2: 42.3 (16) | G2: 24.5 (17) (P < 0.05) | G2: 20.01 (0.8) | G2: 1.74 (0.7) (P = NR)
| | | (P = NS) | | | | | G3: 45.8 (16) | G3: 28.1 (13) (P < 0.05) | G3: 2.38 (0.9) | G3: 1.75 (0.7) (P < 0.05)
| | | Past AN, %: | | | | | G4: 39.9 (16) | G4: 28.7 (23) (P < 0.05) | G4: 20.07 (0.6) | G4: 1.83 (0.8) (P = NR)
| | | G1: 17% | | | | | G5: 40.9 (20) | G5: 27.8 (21) (P < 0.05) | G5: 2.25 (0.7) | G5: 1.73 (0.8) (P < 0.05)
| | | G2: 36% | | | | | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR)
| | | G3: 32% | | | | | | Diff between groups in change over time | | Diff between groups in change over time
| | | G4: 27% | | | | | | G1+G2 better than G3+G4 (P = 0.005) | | G1+G2 vs. G3+G4 (P = NS)
| | | G5: 32% | | | | | | G1+G3 better than G2+G4 (P = 0.01) | | G1+G3 better than G2+G4 (P = 0.05)
| | | (P = NS) | | | | | | G1 better than G5 (P = 0.01) | | G1 vs. G5 (P = NS)
| | | | | | | | | G3 vs. G5 (P = NS) | | G3 vs. G5 (P = NS)
| | | | | | | | BSQ, mean (SD): | BSQ, mean (SD): | SCL-90 Anxiety Index, mean (SD): | SCL-90 Anxiety Index, mean (SD):
| | | | | | | | G1: 137 (29) | G1: 87 (36) (P < 0.05) | G1: 1.83 (0.7) | G1: 1.31 (0.4) (P < 0.05)
| | | | | | | | G2: 132 (32) | G2: 94 (36) (P < 0.05) | G2: 1.57 (0.6) | G2: 1.37 (0.5) (P = NR)
| | | | | | | | G3: 132 (30) | G3: 94 (35) (P < 0.05) | G3: 1.66 (0.6) | G3: 1.37 (0.5) (P < 0.05)
| | | | | | | | G4: 127 (31) | G4: 104 (39) (P < 0.05) | G4: 1.56 (0.5) | G4: 1.41 (0.5) (P = NR)
| | | | | | | | G5: 135 (38) | G5: 106 (47) (P < 0.05) | G5: 1.55 (0.5) | G5: 1.29 (0.4) (P < 0.05)
| | | | | | | | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time | | Diff between groups in change over time
| | | | | | | | | G1+G2 vs. G3+G4 (P = NS) | | G1+G2 vs. G3+G4 (P = NS)
| | | | | | | | | G1+G3 vs. G2+G4 (P = NS) | | G1+G3 vs. G2+G4 (P = NS)
| | | | | | | | | G1 better than G5 (P = 0.05) | | G1 vs. G5 (P = NS)
| | | | | | | | | G3 vs. G5 (P = NS) | | G3 vs. G5 (P = NS)
| | | | | | | | EDE binges/mo, mean (SD): | EDE binges/mo, mean (SD):
| | | | | | | | G1: 28.8 (23) | G1: 2.5 (5) (P < 0.05)
| | | | | | | | G2: 28.1 (22) | G2: 6.6 (14) (P < 0.05)
| | | | | | | | G3: 33.4 (21) | G3: 13.2 (15) (P < 0.05)
| | | | | | | | G4: 21.8 (12) | G4: 10.6 (18) (P < 0.05)
| | | | | | | | G5: 36.8 (35) | G5: 6.1 (14) (P < 0.05)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G1+G2 better than G3+G4 (P = 0.001)
| | | | | | | | | G1+G3 vs. G2+G4 (P = NS)
| | | | | | | | | G1 vs. G5 (P = NS)
| | | | | | | | | G5 better than G3 (P = 0.03)
| | | | | | | | EDE vomiting episodes/mo, mean (SD): | EDE vomit episodes/mo, mean (SD):
| | | | | | | | G1: 38.7 (27) | G1: 3.4 (6) (P < 0.05)
| | | | | | | | G2: 45.9 (69) | G2: 7.6 (17) (P < 0.05)
| | | | | | | | G3: 39.3 (29) | G3: 16.8 (16) (P < 0.05)
| | | | | | | | G4: 41.6 (48) | G4: 25.4 (43) (P < 0.05)
| | | | | | | | G5: 45.4 (38) | G5: 8.9 (13) (P < 0.05)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G1+G2 better than G3+G4 (P = 0.0001)
| | | | | | | | | G1+G3 vs. G2+G4 (P = NS)
| | | | | | | | | G1 better than G5 (P = 0.04)
| | | | | | | | | G5 better G3 (P = 0.03)
| | | | | | | | EDE importance of shape and wt, mean (SD): | EDE importance of shape and wt, mean (SD):
| | | | | | | | G1: 8.43 (2.4) | G1: 7.11 (3.2) (P = NR)
| | | | | | | | G2: 8.56 (2.9) | G2: 6.81 (3.6) (P < 0.05)
| | | | | | | | G3: 9.45 (2.5) | G3: 6.25 (3.3) (P < 0.05)
| | | | | | | | G4: 8.95 (2.5) | G4: 7.71 (3.2) (P = NR)
| | | | | | | | G5: 9.55 (2.2) | G5: 8.45 (2.7) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G1+G2 vs. G3+G4 (P = NS)
| | | | | | | | | G1+G3 vs. G2+G4 (P = NS)
| | | | | | | | | G1 vs. G5 (P = NS)
| | | | | | | | | G5 better than G3 (P = 0.01)
| | | | | | | | EDE shape concern, mean (SD): | EDE shape concern, mean (SD):
| | | | | | | | G1: 3.74 (1.2) | G1: 2.18 (1.4) (P = NR)
| | | | | | | | G2: 3.59 (1.3) | G2: 2.27 (1.3) (P = NR)
| | | | | | | | G3: 3.78 (1.4) | G3: 2.47 (1.5) (P = NR)
| | | | | | | | G4: 3.52 (1.2) | G4: 2.52 (1.5) (P = NR)
| | | | | | | | G5: 3.99 (1.3) | G5: 2.80 (1.4) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G1+G2 vs. G3+G4 (P = NS)
| | | | | | | | | G1+G3 vs. G2+G4 (P = NS)
| | | | | | | | | G1 vs. G5 (P = NS)
| | | | | | | | | G3 vs. G5 (P = NS)
| | | | | | | | EDE wt concern, mean (SD): | EDE wt concern, mean (SD):
| | | | | | | | G1: 3.53 (1.1) | G1: 2.06 (1.4) (P = NR)
| | | | | | | | G2: 3.47 (1.4) | G2: 1.99 (1.4) (P = NR)
| | | | | | | | G3: 3.69 (1.5) | G3: 1.98 (1.5) (P = NR)
| | | | | | | | G4: 3.36 (1.2) | G4: 2.38 (1.7) (P = NR)
| | | | | | | | G5: 3.37 (1.4) | G5: 2.44 (1.4) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G1+G2 vs. G3+G4 (P = NS)
| | | | | | | | | G1+G3 vs. G2+G4 (P = NS)
| | | | | | | | | G1 vs. G5 (P = NS)
| | | | | | | | | G3 vs. G5 (P = NS)
| | | | | | | | EDE restraint, mean (SD): | EDE restraint, mean (SD):
| | | | | | | | G1: 3.21 (1.2) | G1: 1.15 (1.2) (P < 0.05)
| | | | | | | | G2: 3.13 (1.2) | G2: 1.43 (1.4) (P < 0.05)
| | | | | | | | G3: 3.28 (1.3) | G3: 2.06 (1.6) (P < 0.05)
| | | | | | | | G4: 2.93 (1.5) | G4: 1.68 (1.6) (P < 0.05)
| | | | | | | | G5: 3.59 (1.4) | G5: 2.15 (1.5) (P < 0.05)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G1 + G2 vs. G3 + G4 (P = NS)
| | | | | | | | | G1 + G3 vs. G2 + G4 (P = NS)
| | | | | | | | | G1 vs. G5 (P = NS)
| | | | | | | | | G3 vs. G5 (P = NS)
| | | | | | | | EDE overeating, mean (SD): | EDE overeating, mean (SD):
| | | | | | | | G1: 3.26 (0.5) | G1: 1.37 (1.1) (P = NR)
| | | | | | | | G2: 3.18 (0.6) | G2: 1.73 (1.3) (P = NR)
| | | | | | | | G3: 3.32 (0.7) | G3: 2.17 (1.3) (P = NR)
| | | | | | | | G4: 2.99 (0.6) | G4: 1.91 (1.2) (P = NR)
| | | | | | | | G5: 3.18 (0.6) | G5: 1.49 (10.0) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G1 + G2 vs. G3 + G4 (P = NS)
| | | | | | | | | G1 + G3 vs. G2 + G4 (P = NS)
| | | | | | | | | G1 vs. G5 (P = NS)
| | | | | | | | | G3 vs. G5 (P = NS)
| | | | | | | | EDE eating concern, mean (SD): | EDE eating concern, mean (SD):
| | | | | | | | G1: 2.45 (1.6) | G1: 0.84 (1.0) (P < 0.05)
| | | | | | | | G2: 2.36 (1.4) | G2: 0.77 (0.9) (P < 0.05)
| | | | | | | | G3: 2.49 (1.3) | G3: 1.36 (1.6) (P < 0.05)
| | | | | | | | G4: 2.31 (1.3) | G4: 1.32 (1.4) (P < 0.05)
| | | | | | | | G5: 2.58 (1.2) | G5: 1.17 (0.8) (P < 0.05)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G1 + G2 vs. G3 + G4 (P = NS)
| | | | | | | | | G1 + G3 vs. G2 + G4 (P = NS)
| | | | | | | | | G1 vs. G5 (P = NS)
| | | | | | | | | G3 vs. G5 (P = NS)
| | | | | | | | EDE global score, mean (SD): | EDE global score, mean (SD):
| | | | | | | | G1: 3.23 (0.7) | G1: 1.52 (0.9) (P < 0.05)
| | | | | | | | G2: 3.15 (0.7) | G2: 1.65 (0.9) (P < 0.05)
| | | | | | | | G3: 3.31 (0.9) | G3: 2.01 (1.1) (P < 0.05)
| | | | | | | | G4: 3.02 (1.3) | G4: 1.96 (1.2) (P < 0.05)
| | | | | | | | G5: 3.34 (0.7) | G5: 2.01 (0.9) (P < 0.05)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G1 + G2 vs. G3 + G4 (P = NS)
| | | | | | | | | G1 + G3 vs. G2 + G4 (P = NS)
| | | | | | | | | G1 vs. G5 (P = NS)
| | | | | | | | | G3 vs. G5 (P = NS)
| | | | | | | | | Remission of self-report binge eating and vomiting, N (%):
| | | | | | | | | G1: 11/23 (48) (P = NR)
| | | | | | | | | G2: 5/25 (20) (P = NR)
| | | | | | | | | G3: 2/22 (9) (P = NR)
| | | | | | | | | G4: 3/22 (14) (P = NR)
| | | | | | | | | G5: 6/28 (21) (P = NR)
| | | | | | | | | Diff between groups
| | | | | | | | | G1+G2 vs. G3+G4, OR = 4.3 [1.4–13.3] (P = 0.01)
| | | | | | | | | G1+G3 vs. G2+G4 (P = NR)
| | | | | | | | | G1 vs. G5, OR = 3.7 [1.1–12.5] (P = 0.04)
| | | | | | | | | G3 vs. G5 (P = NR)
| | | | | | | | | Remission of EDE binge eating and vomiting, N (%):
| | | | | | | | | G1: 9/18 (50) (P = NR)
| | | | | | | | | G2: 3/16 (19) (P = NR)
| | | | | | | | | G3: 3/17 (18) (P = NR)
| | | | | | | | | G4: 2/17 (12) (P = NR)
| | | | | | | | | G5: 5/20 (25) (P = NR)
| | | | | | | | | Diff between groups
| | | | | | | | | G1+G2 vs. G3+G4, OR = 3.3 [1.0–10.9] (P = 0.06)
| | | | | | | | | G1+G3 vs. G2+G4, OR = 2.7 [1.0–7.5] (P = 0.07)
| | | | | | | | | G1 vs. G5 (P = NR)
| | | | | | | | | G3 vs. G5 (P = NR)
| | | | | | | | | G3 vs. G5 (P = NR)

Evidence Table 7. Behavioral intervention trials for bulimia nervosa

| | | | | | | | Eating Related Measures | | Psychological/Psychiatric Measures | | Biomarkers
Study Description | Objective | Design | Patient Characteristics | Inclusion/Exclusion Criteria | Statistical MethodsTreatment | Quality | | Baseline | Outcomes | Baseline | Outcomes | Baseline | Outcomes
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | 77 enrolled subjects randomized to one of four conditions which were administered over a 4-mo period (i.e., 1-hour long per session, up to 14 sessions). In each of the three tx conditions, subjects met individually with Ph.D. level psychologists. Assessments conducted at baseline, 6 wks, 4 mos for all groups and 6 mo FU for the three tx conditions only. | Repeated measures ANOVAs to evaluate between group diffs in changes in primary (e.g., purging frequency) and secondary (e.g., depression, dieting attitudes, maturity attitudes, and food preoccupation) continuous outcome measures over the course of tx at three different time points (i.e., baseline, 6 wks, 4 mos). Scheffe post-hoc analyses used to interpret sig interaction effects. Chi-square analyses used to assess between group diffs on categorical measures or percentage diffs in variables of interest. The secondary measures were created through principal components analysis of standard depression, anxiety, and eating-related self-report measures. | Score: | Purges/wk, mean (SD): | Purges/wk, mean (SD): | BDI, mean (SD): | BDI, mean (SD): | Wt, kg, mean (SD): | Change in Wt, kg, mean (SD):
Agras et al., 1989 | To compare the efficacy of three, 4-mo long psychological txs (self-monitoring of binge-eating and purging only, CBT, CBT + response prevention of purging behavior) versus a waitlist control for reducing BN symptoms. Another primary objective was to assess whether the addition of a purging-related response prevention component to the CBT tx would yield additional reductions in purging frequency. | G1: waitlist (N = 19) | Total Sample: | DSM III-R criteria for BN; Female; ages 18–65 | | | Fair | G1: 13.8 (8.4) | At 4 mos | G1: 19.5 (7.6) | At 4 mos | G1: NR | At 4 mos
Setting: | | G2: self-monitoring (N = 19) | 29.2 (8.6) (range: 18–61 yrs) | Exclusion: | | | Intent to treat: | G2: 12.3 (8.3) | G1: 13.6 (10.7) (P = NS) | G2: 19.6 (10.2) | G1: 18.8 (8.3) (P = NR) | G2: NR | G1: -2.01 (P = NR)
Single center; outpatient; location: Department of Psychiatry and Behavioral Sciences and the Behavioral Medicine Program, Stanford University School of Medicine; Stanford, CA, USA | | G3: CBT (N = 22) | Sex: | Concurrent psychological or pharmacological tx for BN; concurrent DSM III-R dx of AN, schizophrenia, unipolar or bipolar affective disorder, drug abuse, or alcoholism; pregnancy; abnormal serum potassium; major medical disorders such as hepatic disease, renal disease, or major cardiac disease. | | | No | G3: 11.1 (6.0) | G2: 4.6 (6.2) (P < 0.01) | G3: 18.2 (6.7) | G2: 13.5 (10.2) (P = NR) | G3: NR | G2: +1.64 (P = NR)
Enrollment period: | | G4: CBT + response prevention (N = 17) | Female: 100% | | | | Blinding: | G4: 12.2 (8.3) | G3: 2.8 (6.3) (P < 0.001) | G4: 19.1 (9.4) | G3: 7.1 (7.7) (P = NR) | G4: NR | G3: +0.48 (P = NR)
NR | | Enrollment: | Race/ethnicity: | | | | NA | (P = NS) | G4: 5.8 (10.3) (P < 0.04) | (P = NS) | G4: 9.2 (7.2) (P = NR) | (P = NS) | G4: +3.49 (P = NR)
| | - 119 recruited through media advertisements and through referrals from health care workers were screened; - 77 were enrolled and randomized.; - 67 remained at 4 mo post-tx (G1 = 18, G2 = 16, G3 = 17, G4 = 16) | NR | | | | Adverse events: | | Diff between groups (P = NR) | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | (P = NS) | | | | | NR | Maturity, mean (SD): | Diff between groups in change over time (P < 0.02) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NS)
| | | | | | | Funding: | G1: 7.1 (4.2) | G3 better than G1 (P < 0.05) | | G3, G4 better than G1 (P < 0.05)
| | | | | | | NIMH | G2: 6.3 (5.4) | G2, G4 vs. G1 (P = NS) | | G2 vs. G1 (P = NS)
| | | | | | | | G3: 5.8 (4.2) | At 6-mo FU (% purge reduction):
| | | | | | | | G4: 6.9 (5.4) | G1: NA
| | | | | | | | (P = NS) | G2: 50%
| | | | | | | | | G3: 80%
| | | | | | | | | G4: 50%
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Abstinence of Purging:
| | | | | | | | | At 4 mos
| | | | | | | | | G1: 5.8%
| | | | | | | | | G2: 23.5%
| | | | | | | | | G3: 56.3%
| | | | | | | | | G4: 31.2%
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G3 greater than G1 (P < 0.01)
| | | | | | | | | G2, G4 vs. G1 (P = NS)
| | | | | | | | | At 6-mo FU
| | | | | | | | | G1: NA
| | | | | | | | | G2: 18%
| | | | | | | | | G3: 59%
| | | | | | | | | G4: 20%
| | | | | | | | | Diff between groups (P < 0.005)
| | | | | | | | | G3 greater than G2 and G4
| | | | | | | | Food Preoccupation, mean (SD): | Food Preoccupation, mean (SD):
| | | | | | | | G1: 11.4 (4.4) | At 4 mos
| | | | | | | | G2: 11.8 (3.6) | G1: 9.2 (4.7) (P = NR)
| | | | | | | | G3: 10.4 (3.4) | G2: 8.0 (5.7) (P = NR)
| | | | | | | | G4: 10.9 (4.3) | G3: 2.5 (4.5) (P = NR)
| | | | | | | | (P = NS) | G4: 4.0 (4.0) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | At 6-mo FU
| | | | | | | | | (P = NR)
| | | | | | | | Dieting urges, mean (SD): | Dieting urges, mean (SD):
| | | | | | | | G1: 14.4 (6.3) | At 4 mos
| | | | | | | | G2: 17.7 (6.8) | G1: 13.1 (5.4) (P = NR)
| | | | | | | | G3: 16.8 (4.3) | G2: 14.0 (8.0) (P = NR)
| | | | | | | | G4: 15.5 (6.3) | G3: 8.5 (7.1) (P = NR)
| | | | | | | | (P = NS) | G4: 10.2 (6.6) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | At 6-mo FU
| | | | | | | | | (P = NR)
| | | | | | | | Maturity, mean (SD):
| | | | | | | | G1: 7.1 (4.2)
| | | | | | | | G2: 6.3 (5.4)
| | | | | | | | G3: 5.8 (4.2)
| | | | | | | | G4: 6.9 (5.4)
| | | | | | | | (P = NS)
Author, yr: | Research objective: | Groups enrolled: | Age, yrs, mean (SD): | Inclusion: | CBT and IPT: 19 individual 50-minutes therapy sessions conducted over 20 wks as 2x/wk for 2 wks, wkly for 12 wks, at 2-wk intervals for 6 wks. | Stratification of sample on hx of AN | Score: | | Post-tx | | Post-tx:
Wilson et al., 2002 | To investigate the mechanism by which CBT vs. IPT improves BN symptomatology by examining three potential mediating factors and their time course of action: | G1: CBT (N = 110) | G1: 28.3 (7.0) | DSM III-R criteria for BN | G1: manualized CBT (Fiarburn, Marcus, and Wilson, 1993) | Randomization by Efron's biased coin method at Stanford Data Center | Fair | | Reduction in Vomiting, %: | | Rosenberg Self-Esteem:
Setting: | - reduction in dietary restraint; - change in self-efficacy; - modification of dysfunctional attitudes about body wt and shape | G2: IPT (N = 110) | G2: 27.9 (7.5) | Exclusion: | G2: manualized IPT (Fairburn, in Garner and Garfinkel, 1997) | Multiple linear or logistic regression to test the model: Effect = B1 (main tx effect) + B2 (main mediator effect) + B3 (interactive effect) | Intent to treat: | | G1: 80% | | G1: NR (P = NR)
2 tx sites: | | Enrollment: | (P = NS) | Severe medical or psychiatric condition (e.g., psychosis), current AN, current psych tx of any type, use of any meds known to affect eating or wt, pregnancy, previous exposure to adequate trial of CBT or IPT for BN. | Questionnaires to evaluate dietary restraint, body and wt concerns (EDE-Q (Fairburn and Beglin, 1994), self-efficacy (Rosenberg, 1979, and study-defined SE), interpersonal problems (IIP), and therapeutic alliance (Helping Relationship Questionniare (Laborsky, 1984) were administered at pre-tx, wk 4 (HRQ only) and mid-tx (wk 10). | Tx outcomes included: proportion of subjects recovered (no bingeing or purging in previous 28 days), proportion of subjects remitted (bingeing or purging < 2x/wk in 28 days), frequency of bingeing/purging episodes post-tx and at FU co-varying for pre-tx base rates. | No | | G2: 52% | | G2: NR (P = NR)
Stanford University, Palo Alto, CA; Columbia University, NY, NY, USA Outpatient | | Potential subjects referred to outpatient tx facilities | Sex: | | Every 2 wks, subjects reported vomiting frequency and rated wt and shape dissatisfaction, and conscious food restriction over past 7 days. | | Blinding: | | (P = 0.00) | | (P = NS)
Quality-control center: | | Randomized (N = 220) | Female: NR | | FU (at least 8 mos post-tx) | | No | | Reduction in Binge Eating, %: | | Inventory of Interpersonal Problems:
Oxford University, USA | | G1: 110 (NY = 54; CA = 56) | Race/ethnicity N (%): | | | | Adverse events: | | G1: 80% | | G1: NR (P = NR)
Enrollment period: | | G2: 110 (NY = 56; CA = 54) | White: | | | | 9 withdrawn from tx, 8 of which received meds: 7 for severe depression, 1 for an acute onset of panic disorder. | | G2: 44% | | G2: NR (P = NR)
NR | | Drop-outs: | G1: 87 (79) | | | | Funding: | | (P = 0.017) | | (P = NS)
| | G1: 31 | G2: 81 (74) | | | | NR | | Improvement in EDE Shape Concerns: | | Change in Self-efficacy over eating behavior, wk 10, mean (SD):
| | G2: 25 | (P = NR) | | | | | | G1:(P < 0.01) | | G1: 2.1 (1.8) (P = NR)
| | Analyses based on ‘complete’ data set: | Hispanic: | | | | | | G2:(P < 0.01) | | G2: 0.9 (1.8) (P = NR)
| | Post-tx: N = 154 | G1: 11 (10) | | | | | | (P = NS) | | (P < 0.01)
| | FU: N = 129 | G2: 14 (13) | | | | | | Improvement in EDE Wt Concerns: | | G1 better than G2
| | | (P = NR) | | | | | | G1:(P le; 0.01) | | Change in Self-efficacy over negative affect, wk 10, mean (SD):
| | | African American: | | | | | | G2:(P = 0.001) | | G1: 2.8 (2.5) (P = NR)
| | | G1: 7 (6) | | | | | | (P = NS) | | G2: 1.9 (2.7) (P = NR)
| | | G2: 7 (6) | | | | | | Change in EDE Restraint, wk 4, mean (SD): | | (P = 0.04)
| | | (P = NR) | | | | | | G1: -1.9 (1.9) (P = NR) | | G1 better than G2
| | | Asian: | | | | | | G2: -1.3 (1.9) (P = NR) | | Change in Self-efficacy over shape and wt, wk 10, mean (SD):
| | | G1: 4 (4) | | | | | | (P = 0.04) | | G1: 1.3 (1.6) (P = NR)
| | | G2: 7 (6) | | | | | | G1 better than G2 | | G2: 0.6 (1.6) (P = NR)
| | | (P = NR) | | | | | | Change in EDE Restraint, wk 6, mean (SD): | | (P = 0.03)
| | | American Indian: | | | | | | G1: -2.2 (2.1) (P = NR) | | G1 better than G2
| | | G1: 1 (1) | | | | | | G2: -1.2 (1.7) (P = NR) | | Suitability of tx, mean (SD):
| | | G2: 0 (0) | | | | | | (P < 0.01) | | G1: 12.2 (2.9) (P = NR)
| | | (P = NR) | | | | | | G1 better than G2 | | G2: 13.1 (2.3) (P = NR)
| | | Duration of Binge Eating, mean (SD): | | | | | | Recovered, N: | | (P = 0.03)
| | | G1: 11.5 (7.5) | | | | | | G1: 29 | | G2 better than G1
| | | G2: 11.4 (7.6) | | | | | | G2: 5
| | | (P = NS) | | | | | | (P = NR)
| | | Duration of Purging, mean (SD): | | | | | | Mediator Analyses:
| | | G1: 10.0 (7.2) | | | | | | Binge Eating Frequency:
| | | G2: 9.7 (6.4) | | | | | | G1: NR (P = NR)
| | | (P = NS) | | | | | | G2: NR (P = NR)
| | | Hx of AN, N (%): | | | | | | Tx Main Effect (P < 0.05)
| | | G1: 26 (24) | | | | | | Tx Effect on Wk 4 Dietary Restraint (P < 0.01)
| | | G2: 26 (24) | | | | | | Tx Effect on Wk 6 Dietary Restraint (P < 0.01)
| | | (P = NR) | | | | | | Tx Effect on Wk 10 Self-Efficacy in Response to Food Cues (P < 0.05)
| | | Lifetime major depression, N (%): | | | | | | Tx X Dietary Restraint Effect (P = NS)
| | | G1: 54 (49) | | | | | | Tx X Self-Efficacy Effect (P = NS)
| | | G2: 63 (57) | | | | | | Purge Frequency:
| | | (P = NR) | | | | | | G1: NR (P = NR)
| | | | | | | | | G2: NR (P = NR)
| | | | | | | | | Tx Main Effect (P < 0.01)
| | | | | | | | | Tx Effect on Wk 4 Dietary Restraint (P < 0.05)
| | | | | | | | | Tx Effect on Wk 6 Dietary Restraint (P < 0.01)
| | | | | | | | | Tx Effect on Wk 10 Self-Efficacy in Response to Food Cues (P < 0.01)
| | | | | | | | | Tx Effect on Wk 10 Self-Efficacy in Response to Shape/Wt Cues (P < 0.05)
| | | | | | | | | Tx Effect on Wk 10 Self-Efficacy in Response to Negative Affect (P < 0.05)
| | | | | | | | | Tx X Dietary Restraint Effect (P = NS)
| | | | | | | | | Tx X Self-Efficacy Effect (P = NS)
| | | | | | | | | AT FU:
| | | | | | | | | Reduction in Vomiting, %:
| | | | | | | | | G1: 61%
| | | | | | | | | G2: 62%
| | | | | | | | | (P = NS)
| | | | | | | | | Reduction in Binge Eating, %:
| | | | | | | | | G1: 72%
| | | | | | | | | G2: 70%
| | | | | | | | | (P = NS)
| | | | | | | | | Remained Recovered, N (%):
| | | | | | | | | G1: 19 of 29 (66%)
| | | | | | | | | G2: 4 of 5 (80%)
| | | | | | | | | (P = NR)
| | | | | | | | | Previously Remitted, Recovered, N (%):
| | | | | | | | | G1: 5 of 15 (33%)
| | | | | | | | | G2: 7 of 19 remitted (34%)
| | | | | | | | | (P = NR)
| | | | | | | | | Newly Recovered, N (%):
| | | | | | | | | G1: 2
| | | | | | | | | G2: 6
| | | | | | | | | (P = NR)
| | | | | | | | | Mediator Analyses:
| | | | | | | | | Binge Eating Frequency:
| | | | | | | | | G1: NR (P = NR)
| | | | | | | | | G2: NR (P = NR)
| | | | | | | | | Tx Main Effect (P = NS)
| | | | | | | | | Tx Effect on Wk 4 Dietary Restraint (P < 0.05)
| | | | | | | | | Tx X Dietary Restraint Effect (P = NS)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | 19, 50 minutes sessions of CBT or IPT over 20 wks; Tx occurred 2x/wk in first 2 wks, wkly for next 12 wks, at 2 wk intervals for remaining 6 wks; sessions audiotaped, and 20% randomly selected and monitored by the quality control site. | A power analysis was calculated for the primary outcome variables. For the primary analysis, logistic regression analyses performed at end of tx and at 1yr FU, using site and tx as independent variables. A secondary ANCOVA (with baseline value as the covariate) used to test for tx diffs in “completers only”. Not normally-distributed data (bingeing, purging) were square root transformed prior to analysis. | Score: | Values for total sample (N = 220): | Intent-to-treat analysis: | Completer Analyses: | Completer Analyses: | Completer Analyses: | Completer Analyses:
Agras et al., 2000 | To test whether IPT might be as efficacious as CBT in the tx of women with BN. | G1: CBT (N = 110) | G1: 28.3 (7.0) | Met DSM III-R criteria for BN, dx using SCID | CBT focused on shape, wt, and eating behaviors; IPT focused on non-eating/wt-related personal issues; tx conducted by doctoral level psychologist or psychiatrist. | | Good | EDI measures: | End-of-tx: | SCL-90-R, mean (SD): | SCL-90-R, mean (SD): | BMI, kg/m^2^, mean (SD): | BMI, kg/m^2^, mean (SD):
Companion article: | | G2: IPT (N = 110) | G2: 27.9 (7.5) | Exclusion: | Assessments were taken at baseline, end-of-tx, 4-, 8-and 12-mos FU. | | Intent to treat: | Objective binges/28days, median: | Recovered (no binge or purge in past 28 days), N (%): | G1: 1.1 (0.6) | End-of-tx: | G1: 23.0 (5.0) | End-of-tx:
Wolk and Devlin, 2001 | | Enrollment: | (P = NS) | Severe physical or psychiatric condition that would interfere with tx; current AN; current psychotherapeutic tx of any type; all psychotropic meds; pregnancy; having received adequate trial of CBT or IBT for BN prior to study | | | Yes | G1: 24.5 | G1: 32 (29%) | G2: 1.1 (0.7) | G1: 0.5 (0.5) (P = NR) | G2: 23.0 (4.8) | G1: 23.3 (4.9) (P = NR)
Setting: | | - Participants recruited via advertisement and physician referral; - 923 contacted by phone; 584 screened out primarily due to not meeting BN dx criteria, meds use, and/or disinterest; - 220 enrolled and randomized (110 at each tx site); - 9 withdrawn (6 CBT); - 27% (of 211) did not complete tx (N = 57):; G1: 31 (28%) and G2: 26 (24%); - 154 completed tx; - 129 completed tx and FU G1: (N = 65) G1: (N = 64) | Sex: | | | | Blinding: | G2: 25.5 | G2: 7 (6%) | (P = NS) | G2: 0.5 (0.5) (P = NR) | (P = NS) | G2: 23.0 (4.9) (P = NR)
Two outpatient tx sites: Stanford University, Stanford, California; Columbia University, NY.; USA; Oxford University, UK served as an independent quality control center | | | Female: NR | | | | NA | (P = NS) | Diff between groups (P < 0.001) | | Diff between groups (P = NS) | | Diff between groups (P = NS)
Enrollment period: | | | Race/ethnicity N (%): | | | | Adverse events: | Purges/28days, median: | G1 better than G2 | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
NR | | | White: | | | | 9 withdrawn from tx, 8 of which received meds: 7 for severe depression, 1 for an acute onset of panic disorder. | G1: 33.0 | Remitted (binge or purge < 2/wk in past 28 days), N (%): | | 4-mo FU: | | 4-mo FU:
| | | G1: 87 (79) | | | | Funding: | G2: 49.0 | G1: 53 (48%) | | G1: 0.5 (0.4) (P = NR) | | G1: 23.3 (5.1) (P = NR)
| | | G2: 81 (74) | | | | NIMH and Wellcome Trust Principal FellowshiP grant | (P = 0.003) | G2: 31 (28%) | | G2: 0.6 (0.6) (P = NR) | | G2: 23.2 (4.9) (P = NR)
| | | (P = NR) | | | | | Restraint, mean (SD): | Diff between groups (P = 0.003) | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | Hispanic: | | | | | G1: 3.4 (1.3) | G1 better than G2 | | Diff between groups in change over time (P = NRS) | | Diff between groups in change over time (P = NR)
| | | G1: 11 (10) | | | | | G2: 3.5 (1.2) | Of participants recovered at end-of-tx: | | 8-and 12-mo FU: | | 8-and 12-mo FU:
| | | G2: 14 (13) | | | | | (P = NS) | Recovered at FU, N (%): | | G1: 0.5 (0.6) (P = NR) | | G1: 23.3 (4.9) (P = NR)
| | | (P = NR) | | | | | Shape Concerns, mean (SD): | G1: 21/32 (66%) | | G2: 0.5 (0.6) (P = NR) | | G2: 22.9 (4.1) (P = NR)
| | | African American: | | | | | G1: 3.7 (1.3) | G2: 4/7 (57%) | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | G1: 7 (6) | | | | | G2: 3.8 (1.2) | Diff between groups (P = NS) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | G2: 7 (6) | | | | | (P = NS) | Of participants remitted (but not recovered) at end-or-tx:
| | | (P = NR) | | | | | Wt. Concerns, mean (SD): | Remitted at FU, N (%):
| | | Asian: | | | | | G1: 3.4 (1.4) | G1: 6/21 (29%)
| | | G1: 4 (4) | | | | | G2: 3.4 (1.5) | G2: 8/24 (33%)
| | | G2: 7 (6) | | | | | (P = NS) | Diff between groups (P = NS)
| | | (P = NR) | | | | | Eating Concerns, mean (SD): | Of remaining participants at end of tx:
| | | American Indian: | | | | | G1: 2.4 (1.4) | Recovered at FU, N (%):
| | | G1: 1 (1) | | | | | G2: 2.9 (1.4) | G1: 4/57 (7%)
| | | G2: 0 (0) | | | | | (P = 0.02) | G2: 7/79 (9%)
| | | (P = NR) | | | | | Global Score, mean (SD): | Diff between groups (P = NR)
| | | Duration of binge eating, mean (SD): | | | | | G1: 3.2 (1.0)
| | | G1: 11.5 (7.5) | | | | | G2: 3.3 (0.9)
| | | G2: 11.4 (7.6) | | | | | (P = NS)
| | | (P = NS) | | | | | Completer Analyses: | Completer Analyses:
| | | Duration of purging, mean (SD): | | | | | EDE - Objective binges/28days, median (interquartile range): | EDE - Objective binges/28days, median (interquartile range):
| | | G1: 10.0 (7.2) | | | | | G1: 20.0 (32) | End of tx:
| | | G2: 9.7 (6.4) | | | | | G2: 23.5 (27) | G1: 0 (5) (P = NR)
| | | (P = NS) | | | | | (P = NS) | G2: 5 (23.5) (P = NR)
| | | Hx of AN, N (%): | | | | | | Diff between groups (P = 0.001)
| | | G1: 26 (24) | | | | | | G1 better than G2
| | | G2: 26 (24) | | | | | | Diff between groups in change over time (P = NR)
| | | (P = NR) | | | | | | 4-mo FU:
| | | Lifetime major depression, N (%): | | | | | | G1: 0 (5) (P = NR)
| | | G1: 54 (49) | | | | | | G2: 6 (20) (P = NR)
| | | G2: 63 (57) | | | | | | Diff between groups (P = NS)
| | | (P = NR) | | | | | | Diff between groups in change over time (P = NR)
| | | Current major depression, N (%): | | | | | | 8- or 12-mo FU:
| | | G1: 22 (20) | | | | | | G1: 0 (10) (P = NR)
| | | G2: 25 (23) | | | | | | G2: 2 (17.5) (P = NR)
| | | (P = NR) | | | | | | Diff between groups (P = NS)
| | | Lifetime substance abuse/dependence, N (%): | | | | | | Diff between groups in change over time (P = NR)
| | | G1: 29 (26) | | | | | EDE - Purges/28days, median: | EDE - Purges/28days, median:
| | | G2: 22 (20) | | | | | G1: 30.0 (32) | End of tx:
| | | (P = NR) | | | | | G2: 42.0 (54) | G1: 1.0 (8) (P = NR)
| | | | | | | | (P = 0.001) | G2: 13.5 (32.35) (P = NR)
| | | | | | | | | Diff between groups (P = 0.001)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 4-mo FU:
| | | | | | | | | G1: 1.0 (8.5) (P = NR)
| | | | | | | | | G2: 9.5 (35) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 8- and 12-mo FU:
| | | | | | | | | G1: 3.0 (14.5) (P = NR)
| | | | | | | | | G2: 7.0 (27.5) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE - Restraint, mean (SD): | EDE - Restraint, mean (SD):
| | | | | | | | G1: 3.4 (1.3) | End of tx:
| | | | | | | | G2: 3.3 (1.3) | G1: 1.4 (1.3) (P = NR)
| | | | | | | | (P = NS) | G2: 2.1 (1.4) (P = NR)
| | | | | | | | | Diff between group (P = 0.001)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 4-mo FU:
| | | | | | | | | G1: 1.3 (1.3) (P = NR)
| | | | | | | | | G2: 2.1 (1.5) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 8- and 12-mo FU:
| | | | | | | | | G1: 1.4 (1.5) (P = NR)
| | | | | | | | | G2: 1.8 (1.4) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE - Wt Concerns, mean (SD): | EDE - Wt Concerns, mean (SD):
| | | | | | | | G1: 3.2 (1.4) | End of tx:
| | | | | | | | G2: 3.2 (1.5) | G1: 1.8 (1.2) (P = NR)
| | | | | | | | (P = NS) | G2: 1.9 (1.4) (P = NR)
| | | | | | | | | Diff between group (P = 0.001)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 4-mo FU:
| | | | | | | | | G1: 1.7 (1.2) (P = NR)
| | | | | | | | | G2: 2.0 (1.6) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 8- and 12-mo FU:
| | | | | | | | | G1: 1.8 (1.3) (P = NR)
| | | | | | | | | G2: 1.9 (1.3) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE - Shape Concerns, mean (SD): | EDE - Shape Concerns, mean (SD):
| | | | | | | | G1: 3.5 (1.2) | End of tx:
| | | | | | | | G2: 3.5 (1.4) | G1: 2.1 (1.3) (P = NR)
| | | | | | | | (P = NS) | G2: 2.1 (1.4) (P = NR)
| | | | | | | | | Diff between group (P = 0.001)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 4-mo FU:
| | | | | | | | | G1: 1.8 (1.2) (P = NR)
| | | | | | | | | G2: 2.1 (1.6) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 8- and 12-mo FU:
| | | | | | | | | G1: 1.9 (1.4) (P = NR)
| | | | | | | | | G2: 2.0 (1.4) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE - Eating Concerns, mean (SD): | EDE - Eating Concerns, mean (SD):
| | | | | | | | G1: 2.2 (1.3) | End of tx:
| | | | | | | | G2: 2.6 (1.3) | G1: 0.7 (0.8) (P = NR)
| | | | | | | | (P = NS) | G2: 1.1 (1.1) (P = NR)
| | | | | | | | | Diff between group (P = 0.001)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 4-mo FU:
| | | | | | | | | G1: 0.6 (0.9) (P = NR)
| | | | | | | | | G2: 1.0 (1.0) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 8- and 12-mo FU:
| | | | | | | | | G1: 0.8 (1.2) (P = NR)
| | | | | | | | | G2: 0.9 (1.0) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE - Global Score, mean (SD): | EDE - Global Score, mean (SD):
| | | | | | | | G1: 3.0 (0.9) | End of tx:
| | | | | | | | G2: 3.1 (0.9) | G1: 1.4 (0.9) (P = NR)
| | | | | | | | (P = NS) | G2: 1.8 (1.0) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 4-mo FU:
| | | | | | | | | G1: 1.3 (0.9) (P = NR)
| | | | | | | | | G2: 1.8 (1.1) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 8- and 12-mo FU:
| | | | | | | | | G1: 1.4 (1.1) (P = NR)
| | | | | | | | | G2: 1.6 (1.0) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Reduction of Binge Eating by end-of-tx:
| | | | | | | | | G1: 86%
| | | | | | | | | G2: 51%
| | | | | | | | | Diff between groups (P = 0.01)
| | | | | | | | | G1 better than G2
| | | | | | | | | Reduction of Purging by end-of-tx:
| | | | | | | | | G1: 84%
| | | | | | | | | G2: 50%
| | | | | | | | | Diff between groups (P = 0.001)
| | | | | | | | | G1 better than G2
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | All individuals received 8 sessions of CBT (2 first wk, then wkly) based on manuals. | Binge and purge outcomes: logistic regression controlling for mid-tx measure (end of CBT). | Score: | Abstinence, prior 2 wks: | Abstinence, prior 2 wks: | HDRS, mean (SD): | HDRS, mean (SD):
Bulik, Sullivan, Carter et al., 1998 | - To determine whether addition of ERP to a core of CBT leads to greater clinical improvement and lower risk of relapse.; - To compare efficacy of 2 forms of ERP (ERP to pre-binge cues and ERP to pre-purge cures).; - To determine whether ERP assists with preventing relapse. | G1: exposure to pre-binge cues (B-ERP) (N = 37) | 26.1 (6.1) | Female; age 17–45; current primary DSM III-R dx of BN | Randomized groups: | Clinician rated food restriction and body dissatisfaction outcomes: ordinal logistic regression. | Good | Baseline: | Post-tx: | Baseline: | Post-tx:
Companion article: | | G2: exposure to pre-purge cues (P-ERP) (N = 35) | Sex: | Exclusion: | 2 wks of sessions twice per wk, then 4 wkly sessions; at least 2 performed outside office; min of 50 minutes but lasted until arousal approached baseline (50 m – 3 h). | Continuous outcomes: ANCOVA with main effects of experimental tx, relevant measures at end of CBT as covariates. | Intent to treat: | All groups 0% | G1: 66% (P = NR) | G1: 7.9 (5.5) | G1: 2.6 (3.1) (P = NR)
Carter et al., 2003 and Bulik, Sullivan, Joyce et al., 1998 | | G3: relaxation training (RELAX) (N = 39) | Female: 100% | Current AN, current obesity (BMI>30 kg/m^2^), current severe major depression with severe suicidal ideation or requiring immediate tx with antidepressants, current severe medical illness or severe medical complications of BN, or the current use of psychoactive meds and unwillingness to undergo a supervised drug wash-out period. | G1: B-ERP | All analyses compare B-ERP and P-ERP to RELAX (reference category). | Yes | Mid-tx: | G2: 45% (P = NR) | G2: 7.7 (5.4) | G2: 4.9 (6.0) (P = NR)
Setting: | | Enrollment: | BMI, kg/m^2^, mean (SD): | | G2: P-ERP | | Blinding: | G1: 38% | G3: 47% (P = NR) | G3: 10.1 (5.3) | G3: 6.7 (6.0) (P = NR)
Outpatient, Christchurch, New Zealand | | - 135 began CBT tx; - 116 completed CBT; - 111 randomized to one of the study arms; - 106 completed; - 95 completed 6 mo FU (86% of those randomized); - 105 completed 12 mo FU (95% of those randomized) | 22.4 (2.5) | | G3: (RELAX) | | Post-tx assessor was blinded to tx | G2: 23% | 6 mo FU: | Mid-tx: | 6 mo FU:
Enrollment period: | | Drop-outs: | Race/ethnicity: | | | | Adverse events: | G3: 21% | G1: 53% (P = NR) | G1: 4.4 (4.3) (P = NR) | G1: 3.1 (3.1) (P = NR)
NR | | G1: 2 | White: 91% | | | | NR | (P = NS) | G2: 43% (P = NR) | G2: 5.7 (5.7) (P = NR) | G2: 6.4 (6.5) (P = NR)
| | G2: 2 | Maori, Pacific Island, and Asian: 6% | | | | Funding: | | G3: 51% (P = NR) | G3: 7.5 (5.6) (P = NR) | G3: 5.8 (5.1) (P = NR)
| | G3: 1 | Duration of BN, yrs (SD): | | | | New Zealand Health Research Council and New Zealand Lottery Grants Board | | 12 mo FU: | Diff over time (P < 0.001) | 12 mo FU:
| | | 6.7 (5.8) | | | | | | G1: 65% (P = NR) | Diff between groups (P = NS) | G1: 3.2 (3.0) (P = NR)
| | | Prior BN or Psych Treatment: | | | | | | G2: 44% (P = NR) | | G2: 5.2 (5.5) (P = NR)
| | | 73.6% | | | | | | G3: 43% (P = NR) | | G3: 6.8 (7.6) (P = NR)
| | | Lifetime comorbidity: | | | | | | Abstinence (Clinician Rated), Odds ratio [95% CI] vs. G3: | | HDRS (Clinician Rated), Regression coefficient [95% CI] vs. G3:
| | | Mood: 70.4% | | | | | | Post-tx: | | Post tx:
| | | Anxiety: 61.5% | | | | | | G1: OR = 2.15 [0.65, 7.08] (P = NS) | | G1: -1.35 [-2.46, -0.25] (P = 0.02)
| | | Alcohol use disorders: 48.1% | | | | | | G2: OR = 0.89 [0.28, 2.80] (P = NS) | | G1 better than G3
| | | AN: 25.0% | | | | | | 6 mo FU: | | G2: -0.55 [-1.66, 0.56] (P = NS)
| | | Marital Status: | | | | | | G1: OR = 0.95 [0.34, 2.67] (P = NS) | | 6 mo FU:
| | | Never married or “de facto relationship”: 62.2% | | | | | | G2: OR = 0.67 [0.23, 1.98] (P = NS) | | G1: -1.41 [-3.51, 0.69] (P = NS)
| | | Currently employed: | | | | | | 12 mo FU: | | G2: 1.36 [-1.04, 3.75] (P = NS)
| | | 59.3% | | | | | | G1: OR = 2.59 [0.85, 7.92] (P = NS) | | 12 mo FU:
| | | Education, yrs, mean (SD): | | | | | | G2: OR = 1.11 [0.38, 3.25] (P = NS) | | G1: -2.10 [-4.81, 0.62] (P = NS)
| | | 13.1 (2.6) | | | | | | | | G2: -1.09 [-3.70, 1.51] (P = NS)
| | | | | | | | Bingeing absent prior 2 wks: | Bingeing absent prior 2 wks: | GAFS, mean (SD): | GAFS, mean (SD):
| | | | | | | | Baseline: | Post-tx: | Baseline: | Post-tx:
| | | | | | | | All groups 0% | G1: 66% (P = NR)
| | | | | | | | Mid-tx: | G2: 61% (P = NR) | G1: 56.2 (6.4) | G1: 72.6 (9.7) (P = NR)
| | | | | | | | G1: 51% | G3: 58% (P = NR) | G2: 55.8 (6.7) | G2: 69.0 (10.0) (P = NR)
| | | | | | | | G2: 34% | 6 mo FU: | G3: 55.3 (6.8) | G3: 67.8 (10.1) (P = NR)
| | | | | | | | G3: 36% | G1: 6253% (P = NR) | Mid-tx: | 6 mo FU:
| | | | | | | | (P = NS) | G2: 61% (P = NR) | G1: 65.4 (8.4) (P = NR) | G1: 72.0 (9.2) (P = NR)
| | | | | | | | | G3: 69% P = NR) | G2: 65.0 (8.2) (P = NR) | G2: 67.3 (10.6) (P = NR)
| | | | | | | | | 12 mo FU: | G3: 62.2 (9.9) (P = NR) | G3: 67.0 (11.2) (P = NR)
| | | | | | | | | G1: 68% (P = NR) | Diff over time (P < 0.001) | 12 mo FU:
| | | | | | | | | G2: 56% (P = NR) | Diff between groups (P = NS) | G1: 73.6 (11.1) (P = NR)
| | | | | | | | | G3: 57% (P = NR) | | G2: 67.6 (12.1) (P = NR)
| | | | | | | | | Bingeing absent (Clinician Rated), Odds ratio [95% CI] vs. G3: Post-tx: | | G3: 65.3 (12.7) (P = NR)
| | | | | | | | | G1: OR = 1.36 [0.44, 4.22] (P = NS) | | GAFS (Clinician Rated), Regression coefficient [95% CI] vs. G3:
| | | | | | | | | G2: OR = 1.50 [0.49, 4.64] (P = NS) | | Post tx:
| | | | | | | | | 6 mo FU: | | G1: 1.54 [-0.41, 3.50]
| | | | | | | | | G1: OR = 0.72 [0.24, 2.19] (P = NS) | | (P = NS)
| | | | | | | | | G2: OR = 0.80 [0.25, 2.53] (P = NS) | | G2: -0.12; CI: [-2.10, 1.87]
| | | | | | | | | 12 mo FU: | | (P = NS)
| | | | | | | | | G1: OR = 1.64 [0.56, 4.76] (P = NS) | | 6 mo FU:
| | | | | | | | | G2: OR = 1.09 [0.39, 3.03] (P = NS) | | G1: 3.49 [-1.05, 8.02]
| | | | | | | | Binges/2 wks, mean (SD): | Binges/2 wks, mean (SD): | | (P = NS)
| | | | | | | | Baseine: | Post-tx: | | G2: 0.02 [-4.66, 4.70]
| | | | | | | | G1: 11.7 (10.5) | G1: 1.3 (2.4) (P = NR) | | (P = NS)
| | | | | | | | G2: 9.3 (11.4) | G2: 1.8 (4.1) (P = NR) | | 12 mo FU:
| | | | | | | | G3: 8.6 (9.1) | G3: 1.8 (3.1) (P = NR) | | G1: 5.34 [0.16, 10.5]
| | | | | | | | Mid-tx: | 6 mo FU: | | (P = 0.05) G1 better than G3
| | | | | | | | G1: 2.6 (4.3) (P = NR) | G1: 1.1 (2.6) (P = NR) | | G2: 1.17 [-3.83, 6.17]
| | | | | | | | G2: 2.7 (3.5) (P = NR) | G2: 3.0 (6.4) (P = NR) | | (P = NS)
| | | | | | | | G3: 2.3 (3.2) (P = NR) | G3: 1.2 (2.7) (P = NR)
| | | | | | | | Diff over time (P < 0.001) | 12 mo FU:
| | | | | | | | Diff between groups (P = NS) | G1: 1.7 (3.5) (P = NR)
| | | | | | | | | G2: 2.1 (4.4) (P = NR)
| | | | | | | | | G3: 1.6 (2.4) (P = NR)
| | | | | | | | Purging absent prior 2 wks: | Purging absent prior 2 wks:
| | | | | | | | Baseline: | Post-tx:
| | | | | | | | All groups 0% | G1: 69% (P = NR)
| | | | | | | | Mid-tx: | G2: 55% (P = NR)
| | | | | | | | G1: 46% (P = NR) | G3: 50% (P = NR)
| | | | | | | | G2: 31% (P = NR) | 6 mo FU:
| | | | | | | | G3: 28% (P = NR) | G1: 56% (P = NR)
| | | | | | | | Diff between groups (P = NS) | G2: 50% (P = NR)
| | | | | | | | | G3: 57% (P = NR)
| | | | | | | | | 12 mo FU:
| | | | | | | | | G1: 68% (P = NR)
| | | | | | | | | G2: 47% (P = NR)
| | | | | | | | | G3: 46% (P = NR)
| | | | | | | | | Purging absent (Clinician Rated), Odds ratio [95% CI] vs. G3:
| | | | | | | | | Post-tx:
| | | | | | | | | G1: OR = 2.11 [0.64, 6.94] (P = NS)
| | | | | | | | | G2: OR = 1.10; [0.35, 3.42] (P = NS)
| | | | | | | | | 6 mo FU:
| | | | | | | | | G1: OR = 0.73 [0.25, 2.09] (P = NS)
| | | | | | | | | G2: OR = 0.61 [0.21, 1.83] (P = NS)
| | | | | | | | | 12 mo FU:
| | | | | | | | | G1: OR = 2.13 [0.72, 6.27] (P = NS)
| | | | | | | | | G2: OR = 0.94 [0.33, 2.61] (P = NS)
| | | | | | | | Total purges per 2 wks, mean (SD): | Total purges per 2 wks, mean (SD):
| | | | | | | | Baseline: | Post-tx:
| | | | | | | | G1: 14.4 (11.3) | G1: 2.0 (4.5) (P = NR)
| | | | | | | | G2: 11.0 (13.3) | G2: 2.8 (5.2) (P = NR)
| | | | | | | | G3: 12.4 (11.8) | G3: 5.6 (10.9) (P = NR)
| | | | | | | | Mid-tx: | 6 mo FU:
| | | | | | | | G1: 3.9 (6.0) (P = NR) | G1: 1.5 (2.8) (P = NR)
| | | | | | | | G2: 3.5 (4.6) (P = NR) | G2: 3.8 (6.2) (P = NR)
| | | | | | | | G3: 7.0 (13.3) (P = NR) | G3: 5.3 (10.5) (P = NR)
| | | | | | | | Diff over time (P < 0.001) | 12 mo FU:
| | | | | | | | Diff between groups (P = NS) | G1: 3.2 (8.2) (P = NR)
| | | | | | | | | G2: 3.2 (5.0) (P = NR)
| | | | | | | | | G3: 5.6 (12.1) (P = NR)
| | | | | | | | Vomiting episodes/2 wks, mean (SD): | Vomiting episodes/2 wks, mean (SD):
| | | | | | | | Baseline: | Post-tx:
| | | | | | | | G1: 12.3 (10.9) | G1: 1.9 (4.5) (P = NR)
| | | | | | | | G2: 10.0 (13.4) | G2: 2.4 (4.6) (P = NR)
| | | | | | | | G3: 10.3 (10.8) | G3: 4.4 (9.8) (P = NR)
| | | | | | | | Mid-tx: | 6 mo FU:
| | | | | | | | G1: 3.4 (5.3) (P = NR) | G1: 1.5 (2.8) (P = NR)
| | | | | | | | G2: 3.4 (4.7) (P = NR) | G2: 3.7 (6.2) (P = NR)
| | | | | | | | G3: 5.5 (11.8) (P = NR) | G3: 3.7 (8.6) (P = NR)
| | | | | | | | Diff over time (P = NR) | 12 mo FU:
| | | | | | | | | G1: 3.1 (8.2) (P = NR)
| | | | | | | | | G2: 3.0 (4.9) (P = NR)
| | | | | | | | | G3: 4.5 (11.7) (P = NR)
| | | | | | | | Laxative use episodes/2 wks, mean (SD): | Laxative use episodes/2 wks, mean (SD):
| | | | | | | | Baseline: | Post-tx:
| | | | | | | | G1: 2.1 (5.3) | G1: 0.1 (0.5) (P = NR)
| | | | | | | | G2: 1.0 (2.9) | G2: 0.5 (2.4) (P = NR)
| | | | | | | | G3: 2.1 (4.4) | G3: 1.2 (3.7) (P = NR)
| | | | | | | | Mid-tx: | 6 mo FU:
| | | | | | | | G1: 0.5 (1.5) (P = NR) | G1: 0.0 (0.0) (P = NR)
| | | | | | | | G2: 0.1 (0.4) (P = NR) | G2: 0.1 (0.3) (P = NR)
| | | | | | | | G3: 1.5 (5.1) (P = NR) | G3: 1.7 (5.4) (P = NR)
| | | | | | | | Diff between groups (P = NS) | 12 mo FU:
| | | | | | | | | G1: 0.2 (0.6) (P = NR)
| | | | | | | | | G2: 0.3 (1.0) (P = NR)
| | | | | | | | | G3: 1.1 (3.4) (P = NR)
| | | | | | | | | Peak Subjective Units of Distress (CUE), regression coefficient [95% CI] vs. G3:
| | | | | | | | | Post-tx:
| | | | | | | | | G1: -0.30 [-0.47, -0.12] (P = 0.001)
| | | | | | | | | G1 better than G3
| | | | | | | | | G2: -0.11 [-0.29, 0.07] (P = NS)
| | | | | | | | | Peak Urge To Binge (CUE), regression coefficient [95% CI] vs. G3:
| | | | | | | | | Post-tx:
| | | | | | | | | G1: -0.20 [-0.40, 0.005] (P = NS)
| | | | | | | | | G2: -0.17 [-0.38, 0.00] (P = NS)
| | | | | | | | | Peak Urge To Purge (CUE), regression coefficient [95% CI] vs. G3:
| | | | | | | | | Post-tx:
| | | | | | | | | G1: -0.18 [-0.39, 0.04] (P = NS)
| | | | | | | | | G2: 0.05 [-0.17, 0.27] (P = NS)
| | | | | | | | | Food restriction (Clinician Rated), Odd ratio [95% CI] vs. G3:
| | | | | | | | | Post-tx:
| | | | | | | | | G1: OR = 0.39 [0.16, 1.01] (P = 0.05)
| | | | | | | | | G1 better than G3
| | | | | | | | | G2: OR = 1.00 [0.41, 2.47] (P = NS)
| | | | | | | | | 6 mo FU:
| | | | | | | | | G1: OR = 1.11 [0.44, 2.83] (P = NS)
| | | | | | | | | G2: OR = 1.54 [0.58, 4.10] (P = NS)
| | | | | | | | | 12 mo FU:
| | | | | | | | | G1: OR = 0.30 [0.12, 0.80] (P = 0.02)
| | | | | | | | | G1 better than G3
| | | | | | | | | G2: OR = 0.44 [0.17, 1.10] (P = NS)
| | | | | | | | EDI drive for thinness, mean (SD): | EDI drive for thinness, mean (SD):
| | | | | | | | Baseline: | Post-tx:
| | | | | | | | G1: 14.4 (4.7) | G1: 5.6 (5.7) (P = NR)
| | | | | | | | G2: 14.3 (5.0) | G2: 6.6 (5.6) (P = NR)
| | | | | | | | G3: 13.4 (4.7) | G3: 7.8 (6.6) (P = NR)
| | | | | | | | Mid-tx: | 6 mo FU:
| | | | | | | | G1: 9.3 (6.0) (P = NR) | G1: 4.4 (5.1) (P = NR)
| | | | | | | | G2: 8.5 (5.2) (P = NR) | G2: 6.8 (5.4) (P = NR)
| | | | | | | | G3: 9.4 (6.0) (P = NR) | G3: 5.3 (6.2) (P = NR)
| | | | | | | | Diff over time (P = NR) | 12 mo FU:
| | | | | | | | Diff between groups (P = NS) | G1: 7.1 (6.1) (P = NR)
| | | | | | | | | G2: 5.5 (5.9) (P = NR)
| | | | | | | | | G3: 6.6 (5.9) (P = NR)
| | | | | | | | | EDI drive thinness, regression coefficient [95% CI] vs. G3:
| | | | | | | | | Post-tx:
| | | | | | | | | G1: -1.40 [-2.52, -0.28] (P = 0.01)
| | | | | | | | | G1 better than G3
| | | | | | | | | G2: -0.38 [-1.49, 0.73] (P = NS)
| | | | | | | | | 6 mo FU:
| | | | | | | | | G1: -0.86 [ -3.37, 1.64] (P = NS)
| | | | | | | | | G2: 1.89 [-0.73, 4.51] (P = NS)
| | | | | | | | | 12 mo FU
| | | | | | | | | G1: -0.43 [-3.68, 2.82] (P = NS)
| | | | | | | | | G2: 0.04 [-3.06, 3.15] (P = NS)
| | | | | | | | EDI bulimia, mean (SD): | EDI bulimia, mean (SD):
| | | | | | | | Baseline: | Post-tx:
| | | | | | | | G1: 9.5 (4.1) | G1: 1.5 (3.0) (P = NR)
| | | | | | | | G2: 8.7 (5.5) | G2: 1.6 (2.9) (P = NR)
| | | | | | | | G3: 10.1 (4.3) | G3: 3.3 (3.5) (P = NR)
| | | | | | | | Mid-tx: | 6 mo FU:
| | | | | | | | G1: 3.2 (4.3) (P = NR) | G1: 1.0 (1.8) (P = NR)
| | | | | | | | G2: 3.8 (3.8) (P = NR) | G2: 1.8 (3.6) (P = NR)
| | | | | | | | G3: 4.4 (4.5) (P = NR) | G3: 1.7 (3.0) (P = NR)
| | | | | | | | Diff over time (P = NR) | 12 mo FU:
| | | | | | | | | G1: 2.6 (4.6) (P = NR)
| | | | | | | | | G2: 3.1 (4.9) (P = NR)
| | | | | | | | | G3: 3.1 (4.9) (P = NR)
| | | | | | | | | EDI bulimia, regression coefficient [95% CI] vs. G3:
| | | | | | | | | Post-tx:
| | | | | | | | | G1: -0.60 [-1.23, 0.02] (P = 0.06)
| | | | | | | | | G1 better than G3
| | | | | | | | | G2: -0.77 [-1.38, -0.16] (P = 0.01)
| | | | | | | | | G2 better than G3
| | | | | | | | | 6 mo FU:
| | | | | | | | | G1: -0.32 [-1.69, 1.06] (P = NS)
| | | | | | | | | G2: -0.07 [-1.50, 1.36] (P = NS)
| | | | | | | | | 12 mo FU:
| | | | | | | | | G1: -0.71 [-3.54, 2.11] (P = NS)
| | | | | | | | | G2: 0.44 [-2.25, 3.13] (P = NS)
| | | | | | | | EDI body dissatisfaction, mean (SD): | EDI body dissatisfaction, mean (SD):
| | | | | | | | Baseline: | Post-tx:
| | | | | | | | G1: 18.9 (7.3) | G1: 10.8 (8.9) (P = NR)
| | | | | | | | G2: 18.0 (7.4) | G2: 12.1 (8.2) (P = NR)
| | | | | | | | G3: 18.0 (8.0) | G3: 12.3 (7.8) (P = NR)
| | | | | | | | Mid-tx: | 6 mo FU:
| | | | | | | | G1: 13.3 (8.1) (P = NR) | G1: 8.0 (8.3) (P = NR)
| | | | | | | | G2: 13.4 (7.7) (P = NR) | G2: 13.4 (8.8) (P = NR)
| | | | | | | | G3: 15.0 (8.0) (P = NR) | G3: 10.6 (7.6) (P = NR)
| | | | | | | | Diff over time (P = NR) | 12 mo FU:
| | | | | | | | Diff between groups (P = NS) | G1: 12.2 (8.4) (P = NR)
| | | | | | | | | G2: 11.3 (9.3) (P = NR)
| | | | | | | | | G3: 13.3 (9.2) (P = NR)
| | | | | | | | | EDI body dissatisfaction, regression coefficient [95% CI] vs. G3:
| | | | | | | | | Post-tx:
| | | | | | | | | G1: -0.44 [-1.70, 0.82] (P = NS)
| | | | | | | | | G2: 0.71 [-0.54, 1.96] (P = NS)
| | | | | | | | | 6 mo FU:
| | | | | | | | | G1: -0.29 [-3.58, 3.00] (P = NS)
| | | | | | | | | G2: 3.96 [0.54, 7.37] (P = 0.03)
| | | | | | | | | G1 better than G3
| | | | | | | | | 12 mo FU:
| | | | | | | | | G1: 0.93 [-2.93, 4.79] (P = NS)
| | | | | | | | | G2: 0.79 [CI: -2.89, 4.46] (P = NS)
| | | | | | | | | Body dissatisfaction (Clinician Rated), Odd ratio [95% CI] vs. G3:
| | | | | | | | | Post-tx:
| | | | | | | | | G1: OR = 0.32 [0.13, 0.83] (P = 0.02)
| | | | | | | | | G1 better than G3
| | | | | | | | | G2: OR = 1.46 [0.58, 3.72] (P = NS)
| | | | | | | | | 6 mo FU:
| | | | | | | | | G1: OR = 1.04 [0.42, 2.54] (P = NS)
| | | | | | | | | G2: OR = 1.16 [0.44, 3.01] (P = NS)
| | | | | | | | | 12 mo FU:
| | | | | | | | | G1: 0.74 [0.30, 1.84] (P = NS)
| | | | | | | | | G2: 0.45 [0.18, 1.13] (P = NS)
Author, yr: | To examine predictors of outcome from BN 1 yr after completion of CBT by partitioning predictors temporally into lifetime (including personality), PreTx, and posttx categories. | Groups: | Age, yrs, mean (SD): | Inclusion: | 8 sessions of CBT (2 first wk, then wkly) based on manuals. | Univariate logistic regression, stepwise logistic regression | Score: | | Met DSM III-R criteria for BN in the mo before 1 yr FU:
Bulik, Sullivan, Joyce et al., 1998 | | G1: exposure to pre-binge cues (B-ERP) (N = 37) | 26.5 (6.13) | Female, age: 17 to 45 yrs, primary DSM III-R dx of BN | Randomized groups: | | Fair | | 17%
Companion article: | | G2: exposure to pre-purge cues (P-ERP) (N = 35) | Sex: | Exclusion: | 2 wks of sessions twice per wk, then 4 wkly sessions; at least 2 performed outside office; sessions lasted until arousal approached baseline (min, 50 min, max, 3 hours). | | Intent to treat: | | Bingeing and Purging Episodes, past 3 mos:
Bulik, Sullivan, Carter et al.,1998 and Carter et al., 2003 | | G3: relaxation training (RELAX) (N = 39) | Female: 100% | Current AN; current obesity (BMI > 30); current severe major depression, medical illness, or medical complications of BN; current use of psychoactive meds; unwilling to undergo a supervised drug wash-out period. | G1: B-ERP | | No | | Category 1 (none): 38%
Setting: | | Enrollment: | Race/ethnicity: | | G2: P-ERP | | Blinding: | | Category 2 (not more than 2/wk on avg): 45%
University of Canterbury, New Zealand | | Enrolled (N = 135) | White: 91% | | G3: RELAX | | Post-tx assessor was blinded, however FU assessor blinding is NR. | | Category 3 (2 or more/wk on avg): 16%
Enrollment period: | | Randomized (N = 111) | Maori, Pacific Island, and Asian: 6% | | FU interview inquired about 2 wk episodes throughout the 6 mos. The mean frequency of bingeing and purging per episode in the 3 mos before the 1 yr FU was calculated. | | Adverse events: | | Reported additional tx between end of tx and 1 yr FU:
NR | | Completed tx (N = 106) | Duration of BN, yrs, mean (SD): | | | | NR | | Category 1: 2.6%
| | Completed 12-mo FU (N = 101) | 6.7 (5.8) | | | | Funding: | | Category 2: 6.7%
| | | Lifetime comorbidity: | | | | Original study: New Zealand Health Research Council and New Zealand Lottery Grants Board | | Category 3: 37.5%
| | | Mood: 70.4% | | | | | | Diff between groups (P = 0.002)
| | | Anxiety: 61.5% | | | | | | Poor outcome at 1 yr FU (Predicted by lifetime hx and personality), odds ratio [95% CI]:
| | | Alcohol use disorders: 48.1% | | | | | | G1: 0.32 [0.12 – 0.91]
| | | AN: 25.0% | | | | | | G2: NR
| | | Marital Status: | | | | | | G3: NR
| | | Never married or “de facto relationship”: 62.2% | | | | | | Predicting 1 Yr Outcome with demographics, lifetime hx, and personality:
| | | Currently employed: | | | | | | Univariate Model, predictor, mean (SD) or %, odds ratio [95% CI]:
| | | 59.3% | | | | | | Self-directedness: 24.6 (8.20), 0.94 [0.89 – 0.98] (P < 0.05), higher self-directedness predicts better outcome.
| | | Education, yrs, mean (SD): | | | | | | Age, yrs: 26.5 (6.13), 0.97 [0.91 – 1.03] (P = NS)
| | | 13.1 (2.6) | | | | | | BMI min: 18.6 (2.46), 0.95 [0.81 – 1.10] (P = NS)
| | | | | | | | | Hx of obesity: 8.8%, 2.60 [0.71 – 9.56] (P = NS)
| | | | | | | | | Prior inpatient tx: 9.9%, 0.04 [0.80 – 3.57] (P = NS)
| | | | | | | | | Duration of BN, yrs: 6.82 (6.07), 0.96 [0.91 – 1.03] (P = NS)
| | | | | | | | | Lifetime AN: 24.3%, 1.09 [0.46 – 2.60] (P = NS)
| | | | | | | | | Lifetime major depression: 52.5%, 1.15 [0.55 – 2.41] (P = NS)
| | | | | | | | | Lifetime alcohol dependence: 42.6%, 0.81 [0.38 – 1.72] (P = NS)
| | | | | | | | | Lifetime anxiety disorder: 43.6%, 1.21 [0.57 – 2.56] (P = NS)
| | | | | | | | | Novelty seeking: 21.6 (6.33), 1.00 [0.94 – 1.06] (P = NS)
| | | | | | | | | Harm avoidance: 20.7 (6.89), 1.03 [0.98 – 1.09] (P = NS)
| | | | | | | | | Reward dependence: 15.8 (4.36), 1.03 [0.95 – 1.12] (P = NS)
| | | | | | | | | Persistence: 4.82 (1.98), 1.06 [0.88 – 1.29] (P = NS)
| | | | | | | | | Cooperativeness: 34.1 (5.77), 1.01 [0.95 – 1.06] (P = NS)
| | | | | | | | | Self-transcendence: 11.1 (5.66), 1.00 [0.94 – 1.07] (P = NS)
| | | | | | | | | Total cluster A personality symptoms: 4.12 (3.45), 1.02 [0.91 – 1.14] (P = NS)
| | | | | | | | | Total cluster B symptoms: 7.35 (4.96), 1.07 [0.99 – 1.16] (P = NS)
| | | | | | | | | Total cluster C symptoms: 6.36 (4.64), 1.02 [0.94 – 1.10] (P = NS)
| | | | | | | | | Borderline personality disorder: NR, 1.29 [0.55 – 3.04] (P = NS)
| | | | | | | | | Stepwise Model, predictor, odds ratio [95% CI]:
| | | | | | | | | Hx of Obesity: 7.88 [1.42 – 43.64] (P < 0.05), hx of obesity increased odds of poor outcome
| | | | | | | | | Lifetime hx of alcohol dependence: 0.26 [0.12 – 0.68] (P < 0.05), hx of alcohol dependence decreased odds of poor outcome
| | | | | | | | | Self-directedness: 0.92 [0.87 – 0.98] (P < 0.05), increased self-directedness decreased the odds of poor outcome
| | | | | | | | | Predicting 1 Yr Outcome with Pre-tx Status:
| | | | | | | | | Univariate model, predictor, mean (SD) or %, odds ratio [95% CI]:
| | | | | | | | | GAFS: 55.6 (6.66), 0.91[0.86 – 0.97] (P < 0.05), lower GAFS predicted poorer outcome
| | | | | | | | | EDI, bulimia: 9.61 (4.78), 1.15 [1.05 – 1.25] (P < 0.05), higher EDI bulimia scores predicted poorer outcome
| | | | | | | | | Major depression, past mo: 23%, 3.54 [1.39 – 9.01] (P < 0.05)
| | | | | | | | | Greater current major depression predicted poorer outcome
| | | | | | | | | Binges past 2 wks: 10.6 (11.5), 1.03 [0.99 – 1.06] (P = NS)
| | | | | | | | | Total purges per 2-wk period: 14.7 (20.8), 1.03 [1.00 – 1.06] (P = NS)
| | | | | | | | | Food restriction (quartiles: 3 = 24%; 2 = 29%; 1 = 33%; 0 = 14%): 1.29 [0.88 – 1.88] (P = NS)
| | | | | | | | | Body dissatisfaction (quartiles: 3 = 37%; 2 = 35%; 1 = 24%; 0 = 4%): 0.97 [0.64 – 1.49] (P = NS)
| | | | | | | | | HDRS: 8.75 (5.39), 1.07 [0.99 – 1.15] (P = NS)
| | | | | | | | | EDI drive for thinness: 14.3 (4.64), 1.09 [1.00 – 1.19] (P = NS)
| | | | | | | | | EDI body dissatisfaction: 18.9 (7.50), 1.03 [0.98 – 1.08] (P = NS)
| | | | | | | | | Peak SUDS: 1.67 (0.83), 1.45 [0.68 – 3.12] (P = NS)
| | | | | | | | | Peak urge to binge: 2.44 (0.50), 1.68 [1.05 – 2.69] (P = NS)
| | | | | | | | | Peak urge to purge: 2.04 (0.95), 1.34 [0.89 – 1.98] (P = NS)
| | | | | | | | | Alcohol dependence, past mo: 16%, 1.16 [0.42 – 3.18] (P = NS)
| | | | | | | | | Stepwise model, predictor, odds ratio [95% CI]:
| | | | | | | | | GAFS: 0.93 [0.86 – 0.99] (P < 0.05), increased GAFS increased odds of a good outcome
| | | | | | | | | EDI bulimia: 1.16 [1.06 – 1.27] (P < 0.05), increased EDI bulimia scale increased the odds of poor outcome
| | | | | | | | | Major depression, past mo: 2.80 [1.04 – 7.52] (P < 0.05), presence of major depression at PreTx increased the odds of poor outcome Body dissatisfaction (quartiles): 0.67 [0.41 – 1.08] (P = NS)
| | | | | | | | | Predicting 1 Yr Outcome with Post-tx Status:
| | | | | | | | | Univariate model, predictor, mean (SD) or %, odds ratio [95% CI]:
| | | | | | | | | Binges past 2 wks: 1.58 (3.24), 1.30 [1.11 – 1.51] (P < 0.05), higher binge frequency predicted poorer outcome.
| | | | | | | | | Food restriction (quartiles: 3 = 5%; 2 = 15%; 1 = 34%; 0 = 46%): 2.45 [1.51 – 3.96] (P < 0.05)
| | | | | | | | | Greater food restriction predicted poorer outcome
| | | | | | | | | Body dissatisfaction (quartiles: 3 = 11%; 2 = 24%; 1 = 52%; 0 = 13%): 3.25 [1.89 – 5.58] (P < 0.05)
| | | | | | | | | Greater body dissatisfaction predicted poorer outcome
| | | | | | | | | GAFS: 69.6 (9.85), 0.90 [0.86 – 0.95] (P < 0.05), lower GAFS predicted poorer outcome
| | | | | | | | | HDRS: 5.15 (5.64), 1.11 [1.04 – 1.20] (P < 0.05), higher HDRS predicted poorer outcome
| | | | | | | | | EDI drive for thinness: 6.69 (6.08), 1.15 [1.07 – 1.24] (P < 0.05), higher EDI drive for thinness predicted poorer outcome
| | | | | | | | | EDI bulimia: 2.23 (3.26), 1.23[1.09 – 1.40] (P < 0.05), higher EDI bulimia scores predicted poorer outcome
| | | | | | | | | Peak SUDS: 1.68 (0.83), 1.79 [1.09 – 2.94] (P < 0.05), higher peak SUDS predicted poorer outcome
| | | | | | | | | Peak urge to binge: 0.79 (0.92), 2.11 [1.34– 3.34] (P < 0.05), higher peak urge to binge predicted poorer outcome
| | | | | | | | | Peak urge to purge: 0.80 (0.98), 2.81 [1.76 – 4.47] (P < 0.05), higher peak urge to purge predicted poorer outcome
| | | | | | | | | EDI body dissatisfaction: 11.9 (8.22), 1.05 [1.00 – 1.10] (P = NS)
| | | | | | | | | Total purges per 2-wk period: 3.67 (8.03), 1.10 [1.03 – 1.18] (P = NS)
| | | | | | | | | Stepwise model, odds ratio [95% CI]:
| | | | | | | | | Binges past 2 wks: 1.23 [1.06 – 1.42] (P < 0.05), higher binge frequency predicted poorer outcome
| | | | | | | | | Food restriction (quartiles): 2.35 [1.38 – 4.01] (P < 0.05)
| | | | | | | | | Greater food restriction predicted poorer outcome
| | | | | | | | | Peak urge to binge: 2.06 [1.24 – 3.43] (P < 0.05)
| | | | | | | | | Greater urge to binge predicted poorer outcome
Author, yr: | To evaluate 3-yr outcome of an RCT that compared the additive efficacy of exposure based behavioral txs versus non-exposure based behavioral txs with a core of CBT. | Groups: | Age, yrs, mean (SD): | Inclusion: | 8 sessions of CBT (2 first wk, then wkly) based on manuals. | Non-parametric (Kruskal-Wallis) ANOVA to evaluate outcomes in groups defined by tx completion (G4, G5, G6). Chi-square tests to compare eating-related dx at FU in G4 vs. G5 vs. G6. Separate series of repeated measures ANOVAs to evaluate outcomes in groups that completed CBT and BT (series 1: G1 vs. G3; series 2: G2 vs. G3). | Score: | Binge frequency, past 2 wks, median (range): | Binge frequency, past 2 wks, median (range): | HRDS, median (range): | HDRS, median (range):
Carter et al., 2003 | | G1: exposure to pre-binge cues (B-ERP) (N = 37) | 26.1 (6.1) | Female; age 17–45; current primary DSM III-R dx of BN | Randomized groups: | | Good | NR | Post-tx: | NR | Post-tx:
Companion article: | | G2: exposure to pre-purge cues (P-ERP) (N = 35) | Sex: | Exclusion: | 2 wks of sessions twice per wk, then 4 wkly sessions; at least 2 performed outside office; min of 50 minutes but lasted until arousal approached baseline (50 minutes– 3 h). | | Intent to treat: | | G1: 0.0 (0.0 – 10.0) (P = NR) | | G1: 2.0 (0.0 –14.0) (P = NR)
Bulik, Sullivan, Carter et al., 1998 and Bulik, Sullivan, Joyce et al., 1998 | | G3: relaxation training (RELAX) (N = 39) | Female: 100% | Current AN, current obesity (BMI>30 kg/m^2^), current severe major depression with severe suicidal ideation or requiring immediate tx with antidepressants, current severe medical illness or severe medical complications of BN, or the current use of psychoactive meds and unwillingness to undergo a supervised drug wash-out period. | G1: B-ERP | | Yes | | G2: 0.0 (0.0 – 20.0) (P = NR) | | G2: 3.0 (0.0 – 24.0) (P = NR)
Setting: | | Enrollment: | Race/ethnicity: | | G2: P-ERP | | Blinding: | | G3: 0.0 (0.0 – 12.0) (P = NR) | | G3: 7.0 (0.0 – 19.0) (P = NR)
Outpatient, Christchurch, New Zealand | | Completed 3 yr FU (N = 113) | White: 91% | | G3: (RELAX) | | Assessor, at post-tx only. | | 3 Yr FU: | | 3 Yr FU:
Enrollment period: | | - G1: Completed B-ERP and 3 yr FU (N = 23); - G2: Completed P-ERP and 3 yr FU (N = 27); - G3: Completed RELAX and 3 yr FU (N = 30); - G4: Completed CBT and BT interventions and 3 yr FU (N = 92); - G5: Completed CBT and 3 yr FU but not BT (N = 15); - G6: Completed 3 yr FU but not CBT or BT (N = 6) | Maori, Pacific Island | | | | Adverse events: | | G1: 0.0 (0.0 – 20.0) (P = NR) | | G1: 2.0 (0.0 – 19.0) (P = NR)
NR | | | Asian: 6% | | | | NA | | G2: 0.0 (0.0 – 12.0) (P = NR) | | G2: 6.0 (0.0 – 23.0) (P = NR)
| | | | | | | Funding: | | G3: 0.0 (0.0 – 28.0) (P = NR) | | G3: 4.0 (0.0 – 18.0) (P = NR)
| | | | | | | Health Research Council of New Zealand and the New Zealand Lottery Grants Board | | Diff between groups (P = NS) | | Diff between groups (P = 0.008)
| | | | | | | | | Diff between groups in change over time (P = NS) | | G1 better than G3
| | | | | | | | | G4: 0.0 (0.0 – 28.0) (P = NR) | | Diff between groups in change over time (P = 0.02)
| | | | | | | | | G5: 0.0 (0.0 – 4.0) (P = NR) | | G3 better than G1 (G1 benefit at post-tx not maintained at FU)
| | | | | | | | | G6: 5.5 (1.0 – 30.0) (P = NR) | | Diff between groups in change over time (P = 0.03),
| | | | | | | | | Diff between groups (P < 0.05) | | G3 better than G2 (G2 NS advantage at post-tx and G3 NS advantage at FU)
| | | | | | | | | G1 and G2 better than G6 | | G4: 3.5 (0.0 – 23.0) (P = NR)
| | | | | | | | Vomiting frequency, past 2 wks, median (range): | Vomit frequency, past 2 wks, median (range): | | G5: 4.0 (0.0 – 31.0) (P = NR)
| | | | | | | | NR | Post-tx: | | G6: 7.0 (0.0 – 20.0) (P = NR)
| | | | | | | | | G1: 0.0 (0.0 – 10.0) (P = NR) | | Diff between groups (P = NS)
| | | | | | | | | G2: 0.0 (0.0 – 20.0) (P = NR) | GAF, median (range): | GAF median (range):
| | | | | | | | | G3: 0.0 (0.0 – 12.0) (P = NR) | NR | Post-tx:
| | | | | | | | | 3 Yr FU: | | G1: 75.0 (51.0–88.0) (P = NR)
| | | | | | | | | G1: 0.0 (0.0 – 20.0) (P = NR) | | G2: 70.0 (52.0 – 85.0) (P = NR)
| | | | | | | | | G2: 0.0 (0.0 – 12.0) (P = NR) | | G3: 70.0 (50.0 – 82.0) P = NR)
| | | | | | | | | G3: 0.0 (0.0 – 42.0) (P = NR) | | 3 Yr FU:
| | | | | | | | | Diff between groups (P = NS) | | G1: 70.0 (45.0 – 90.0) (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS) | | G2: 68.0 (40.0 – 90.0) (P = NR)
| | | | | | | | | G4: 0.0 (0.0 – 42.0) (P = NR) | | G3: 64.0 (50.0 – 90.0) (P = NR)
| | | | | | | | | G5: 0.0 (0.0 – 6.0) (P = NR) | | Diff between groups (P = NS)
| | | | | | | | | G6: 5.5 (1.0 – 30.0) (P = NR) | | Diff between groups in change over time (P = NS)
| | | | | | | | | Diff between groups (P < 0.05) | | G4: 68.5 (40.0 – 49.0) (P = NR)
| | | | | | | | | G4 and G5 better than G6 | | G5: 74.0 (55.0 – 89.0) (P = NR)
| | | | | | | | Purge frequency, past 2 wks, median (range): | Purge frequency, past 2 wks, median (range): | | G6: 51.0 (35.0 – 65.0) (P = NR)
| | | | | | | | NR | Post-tx: | | Diff between groups (P < 0.05)
| | | | | | | | | G1: 0.0 (0.0 – 10.0) (P = NR) | | G4 and G5 better t han G6
| | | | | | | | | G2: 0.0 (0.0 – 20.0) (P = NR)
| | | | | | | | | G3: 0.0 (0.0 – 25.0) (P = NR)
| | | | | | | | | 3 Yr FU:
| | | | | | | | | G1: 0.0 (0.0 – 20.0) (P = NR)
| | | | | | | | | G2: 0.0 (0.0 – 12.0) (P = NR)
| | | | | | | | | G3: 0.0 (0.0 – 42.0) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | G4: 0.0 (0.0 – 42.0) (P = NR)
| | | | | | | | | G5: 0.0 (0.0 – 6.0) (P = NR)
| | | | | | | | | G6: 5.5 (1.0 – 35.0) (P = NR)
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G4 and G5 better than G6
| | | | | | | | Dieting, median (range): | Dieting, median (range):
| | | | | | | | NR | Post-tx:
| | | | | | | | | G1: 0.0 (0.0 – 28.0) (P = NR)
| | | | | | | | | G2: 1.0 (0.0 – 28.0) (P = NR)
| | | | | | | | | G3: 2.0 (0.0 – 42.0) (P = NR)
| | | | | | | | | 3 Yr FU:
| | | | | | | | | G1: 3.0 (0.0 – 42.0) (P = NR)
| | | | | | | | | G2: 0.0 (0.0 – 42.0) (P = NR)
| | | | | | | | | G3: 5.5 (0.0 – 42.0) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | G4: 3.5 (0.0 – 42.0) (P = NR)
| | | | | | | | | G5: 0.0 (0.0 – 28.0) (P = NR)
| | | | | | | | | G6: 28.0 (0.0 – 42.0) (P = NR)
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G4 and G5 better than G6
| | | | | | | | Body dissatisfaction, median (range): | Body dissatisfaction, median (range):
| | | | | | | | NR | Post-tx:
| | | | | | | | | G1: 5.0 (0.0 – 28.0) (P = NR)
| | | | | | | | | G2: 14.0 (0.0 – 42.0) (P = NR)
| | | | | | | | | G3: 12.0 (0.0 – 42.0) (P = NR)
| | | | | | | | | 3 Yr FU:
| | | | | | | | | G1: 8.0 (0.0 – 42.0) (P = NR)
| | | | | | | | | G2: 3.0 (0.0 – 42.0) (P = NR)
| | | | | | | | | G3: 3.5 (0.0 – 42.0) (P = NR)
| | | | | | | | | Diff over time (P = 0.005)
| | | | | | | | | G2 and G3 better at FU
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = 0.02)
| | | | | | | | | G3 better than G1 (benefit of G1 at post-tx not maintained at FU)
| | | | | | | | | G4: 4.0 (0.0 – 42.0) (P = NR)
| | | | | | | | | G5: 2.0 (0.0 – 28.0) (P = NR)
| | | | | | | | | G6: 17.0 (10.0 – 42.0) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | EDI Drive for thinness, median (range): | EDI Drive for thinness, median (range):
| | | | | | | | NR | Post-tx:
| | | | | | | | | G1: 4.0 (0.0 – 17.0) (P = NR)
| | | | | | | | | G2: 6.0 (0.0 – 17.0) (P = NR)
| | | | | | | | | G3: 4.0 (0.0 – 19.0) (P = NR)
| | | | | | | | | 3 Yr FU:
| | | | | | | | | G1: 1.0 (0.0 – 23.0) (P = NR)
| | | | | | | | | G2: 2.0 (0.0 – 19.0) (P = NR)
| | | | | | | | | G3: 2.0 (0.0 – 15.0) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | G4: 2.0 (0.0 – 23.0) (P = NR)
| | | | | | | | | G5: 2.0 (0.0 – 15.0) (P = NR)
| | | | | | | | | G6: 16.0 (0.0 – 12.0) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | EDI Bulimia, median (range): | EDI Bulimia, median (range):
| | | | | | | | NR | Post-tx:
| | | | | | | | | G1: 0.0 (0.0 – 12.0) (P = NR)
| | | | | | | | | G2: 0.0 (0.0 – 10.0) (P = NR)
| | | | | | | | | G3: 2.0 (0.0 – 12.0) (P = NR)
| | | | | | | | | 3 Yr FU:
| | | | | | | | | G1: 0.0 (0.0 – 34.0) (P = NR)
| | | | | | | | | G2: 0.0 (0.0 – 14.0) (P = NR)
| | | | | | | | | G3: 0.0 (0.0 – 17.0) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.04)
| | | | | | | | | G3 better than G2 (G2 benefit at post-tx not maintained at FU)
| | | | | | | | | G4: 0.0 (0.0 – 34.0) (P = NR)
| | | | | | | | | G5: 0.0 (0.0 – 15.0) (P = NR)
| | | | | | | | | G6: 7.0 (0.0 – 15.0) (P = NR)
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G4 better than G6
| | | | | | | | EDI Body dissatisfaction, median (range): | EDI Body dissatisfaction, median (range): Post-tx:
| | | | | | | | NR | G1: 5.0 (0.0 –23.0) (P = NR)
| | | | | | | | | G2: 10.0 (0.0 – 27.0) (P = NR)
| | | | | | | | | G3: 12.50 (0.0 – 27.0) (P = NR)
| | | | | | | | | 3 Yr FU:
| | | | | | | | | G1: 8.0 (0.0 – 34.0) (P = NR)
| | | | | | | | | G2: 5.0 (0.0 – 27.0) (P = NR)
| | | | | | | | | G3: 7.0 (0.0 – 27.0) (P = NR)
| | | | | | | | | Diff over time (P = 0.004)
| | | | | | | | | G2 and G3 better vs. post-tx
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | G4: 7.0 (0.0 – 34.0) (P = NR)
| | | | | | | | | G5: 3.0 (0.0 – 25.0) (P = NR)
| | | | | | | | | G6: 15.0 (6.0 – 24.0) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Eating-related dx
| | | | | | | | | BN Current (%):
| | | | | | | | | G4: 12
| | | | | | | | | G5: 7
| | | | | | | | | G6: 83
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G4 and G5 better than G6
| | | | | | | | | BN Last Yr (%):
| | | | | | | | | G4: 16
| | | | | | | | | G5: 27
| | | | | | | | | G6: 83
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G4 and G5 better than G6
| | | | | | | | | AN Current (%):
| | | | | | | | | G4: 1
| | | | | | | | | G5: 0
| | | | | | | | | G6: 0
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | AN Last Yr (%):
| | | | | | | | | G4: 1
| | | | | | | | | G5: 13
| | | | | | | | | G6: 0
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | EDNOS Current (%):
| | | | | | | | | G4: 15
| | | | | | | | | G5: 13
| | | | | | | | | G6: 17
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | EDNOS Last Yr (%):
| | | | | | | | | G4: 20
| | | | | | | | | G5: 27
| | | | | | | | | G6: 17
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Any ED Current (%):
| | | | | | | | | G4: 28
| | | | | | | | | G5: 20
| | | | | | | | | G6: 100
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G4 and G5 better than G6
| | | | | | | | | Any ED Last Yr (%):
| | | | | | | | | G4: 35
| | | | | | | | | G5: 53
| | | | | | | | | G6: 100
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G4 and G5 better than G6
Author, yr: | To develop the Oxford University individual CBT (ICBT) manual into a group format (GCBT) and compare them on measures of binge eating, purging, dietary restraint, wt and shape attitudes, eating disorder attitudes, and general pathology at post-tx, and at 3- and 6-mo FU | Groups | Age, yrs, mean (SD): | Inclusion: | Pre-tx, post-tx, and FU assessments | Randomized block design with 6 consecutive subjects per unit randomized to either ICBT or GCBT using random digits (Pocock, 1983). | Score: | Objective Binge Episodes, past 28 days, mean (SD): | Objective Binge Episodes, past 28 days, mean (SD): | State Anxiety, mean (SD): | State Anxiety, mean (SD): | BMI, mean (SD): | BMI, mean (SD):
Chen et al., 2003 | | G1: ICBT (N = 30) | 25.80 (7.24) | Female, 18 yrs or older, BN via DSM IV, BMI = 19 to 27 kg/m2 | G1 (ICBT): 19, 50-minutes sessions based on Oxford semi-structured, 3 stage CBT program (Fairburn et al., 1993), over 4.5 mos, with optional self-help book (Fairburn, 1995) and information session with friends and family | A priori power calculation estimated 30 subjects per group | Fair | G1: 32.07 (23.85) | Post-tx: | G1: 50.8 (10.38) | Post-tx: | G1: 22.0 (2.1) | Post-tx:
Setting: | | G2: GCBT (N = 30) | Sex: | Exclusion: | G2 (GCBT): 19, 90-minutes closed-group sessions adapted from ICBT program with identical handouts, content, and optional material over 4.5 mos; min 6 subjects per group | 2 group x 4 time-points repeated measures MANOVA with correction for multiple comparisons and post-hoc contrasts to assess change over time. | Intent to treat: | G2: 28.17 (25.47) | G1: 7.77 (12.88) (P = NR) | G2: 48.70 (11.22) | G1: 45.23 (11.60) (P = NR) | G2: 22.4 (3.4) | G1: 22.2 (2.3) (P = NR)
Outpatient | | Enrollment: | 100% female | Current BN tx, current suicide risk, medically unstable, other psychiatric comorbid dx, lived more than 1.5 hr away from test site | Both txs conducted by same investigator; all sessions audiotaped. | Chi square test for categorical variables. | Yes | (P = NS) | G2: 10.57 (17.84) (P = NR) | (P = NS) | G2: 43.87 (9.87) (P = NR) | Diff between groups | G2: 22.4 (3.3) (P = NR)
Sydney, Australia | | Subjects recruited from University-affiliated hospital ED programs and general practitioners in the local area | Race/ethnicity: | | 3- and 6-mo FU | Tx suitability ratings by patients and random, independent rater validations of 16.6% of EDE and 10% of therapy sessions | Blinding: | | 3 Mo FU: | | 3 Mo FU: | (P = NS) | 3 Mo FU:
Enrollment period: | | Referred: N = 153 | NR | | | | No | | G1: 8.80 (14.22) (P = NR) | | G1: 45.77 (11.21) (P = NR) | | G1: 22.0 (2.1) (P = NR)
NR | | Presented for general psych assessment: N = 125 | BN Duration, yrs, mean (SD): | | | | Adverse events: | | G2: 7.33 10.62) (P = NR) | | G2: 45.70 (9.30) (P = NR) | | G2: 22.6 (3.0) (P = NR)
| | Eligible: N = 94 | 9.6 (7.26) | | | | Alcohol abuse (N = 2) | | 6 Mo FU: | | 6 Mo FU: | | 6 Mo FU:
| | Presented for BN symptom assessment: and randomized: N = 71 | BN Behaviors, N (%): | | | | AN (N = 1) | | G1: 10.47 (14.24) (P = NR) | | G1: 48.46 (10.67) (P = NR) | | G1: 22.3 (2.5) (P = NR)
| | Enrolled: N = 60 | Purging, 55 (92%) | | | | Visual hallucinations (N = 1) | | G2: 9.60 (14.60) (P = NR) | | G2: 42.43 (11.37) (P = NR) | | G2: 22.3 (2.9) (P = NR)
| | Dropouts: | Vomiting, 55 (92%) | | | | Funding: | | Diff over time (P = NR) | | Diff over time (P = 0.02) | | Diff over time (P = NS)
| | During tx: N = 16 | Laxative abuse, 19 (32%) | | | | Australian Research Council, Australian Postgraduate Award, Welcome Trust Principal Research FellowshiP Award | | Diff between groups (P = NS) | | Diff between group (P = NS) | | Diff between groups (P = NS)
| | G1: 27% | Diuretic abuse, 3 (5%) | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = 0.04) | | Diff between groups in change over time (P = NS)
| | G2: 27% | Overexercise, 27 (45%) | | | | | Subjective, mean (SD): | Subjective, mean (SD): | | G2 better than G1
| | By 3 mo FU: N = 21 | > one form, 32 (53%) | | | | | G1: 14.97 (41.31) | Post-tx: | Trait Anxiety, mean (SD): | Trait Anxiety, mean (SD):
| | By 6 mo FU: N = 23 | Treatment Hx, N (%): | | | | | G2: 10.57 (15.72) | G1: 5.57 (15.49) (P = NR) | G1: 55.33 (9.11) | Post-tx:
| | | ED tx, 32 (53%) | | | | | (P = NS) | G2: 9.83 (18.57) (P = NR) | G2: 55.33 (8.15) | G1: 51.87 (9.09) (P = NR)
| | | Psych tx, 28 (47%) | | | | | | 3 Mo FU: | (P = NS) | G2: 50.97 (8.90) (P = NR)
| | | Psychiatric Hx, N (%): | | | | | | G1: 2.37 (4.94) (P = NR) | | 3 Mo FU:
| | | Past depression, 39 (65%) | | | | | | G2: 9.00 (16.87) (P = NR) | | G1: 52.60 (8.50) (P = NR)
| | | Past self-harm, 16 (30%) | | | | | | 6 Mo FU: | | G2: 52.33 (9.48) (P = NR)
| | | Past substance abuse, 19 (32%) | | | | | | G1: 4.30 (11.17) (P = NR) | | 6 Mo FU:
| | | Current substance abuse, 9 (15%) | | | | | | G2: 8.79 (17.21) (P = NR) | | G1: 52.53 (8.24) (P = NR)
| | | | | | | | | Diff over time (P = NS) | | G2: 49.93 (10.02) (P = NR)
| | | | | | | | | Diff between groups (P = NS) | | Diff over time (P = 0.03)
| | | | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Objective and Subjective, mean (SD): | Objective and Subjective, mean (SD): | BDI, mean (SD): | BDI, mean (SD):
| | | | | | | | G1: 47.03 (45.87) | Post-tx: | G1: 22.00 (9.69) | Post-tx:
| | | | | | | | G2: 38.73 (31.99) | G1: 13.33 (19.24) (P = NR) | G2: 22.70 (10.57) | G1: 15.37 (11.91) (P = NR)
| | | | | | | | (P = NS) | G2: 20.40 (29.82) (P = NR) | (P = NS) | G2: 14.33 (10.36) (P = NR)
| | | | | | | | | 3 Mo FU: | | 3 Mo FU:
| | | | | | | | | G1: 11.17 (14.34) (P = NR) | | G1: 16.73 (11.93) (P = NR)
| | | | | | | | | G2: 16.33 (17.91) (P = NR) | | G2: 14.17 (10.18) (P = NR)
| | | | | | | | | 6 Mo FU: | | 6 Mo FU:
| | | | | | | | | G1: 14.77 (16.64) (P = NR) | | G1: 16.70 (12.74) (P = NR)
| | | | | | | | | G2: 20.03 (25.23) (P = NR) | | G2: 13.37 (10.68) (P = NR)
| | | | | | | | | Diff over time (P < 0.001) | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | | Purging episodes, past 28 days: | Purging episodes, past 28 days: | SCL-90R (Global), mean (SD): | SCL-90R (Global), mean (SD):
| | | | | | | | Vomiting, mean (SD): | Vomiting, mean (SD): | G1: 1.28 (0.55) | Post-tx:
| | | | | | | | G1: 41.70 (48.79) | Post-tx: | G2: 1.45 (0.63) | G1: 1.03 (0.67) (P = NR)
| | | | | | | | G2: 31.20 (34.08) | G1: 8.73 (16.39) (P = NR) | (P = NS) | G2: 1.08 (0.75) (P = NR)
| | | | | | | | (P = NS) | G2: 18.83 (53.49) (P = NR) | | 3 Mo FU:
| | | | | | | | | 3 Mo FU: | | G1: 1.05 (0.68) (P = NR)
| | | | | | | | | G1: 10.57 (16.89) (P = NR) | | G2: 1.12 (0.72) (P = NR)
| | | | | | | | | G2: 10.77 (15.66) (P = NR) | | 6 Mo FU:
| | | | | | | | | 6 Mo FU: | | G1: 1.11 (0.71) (P = NR)
| | | | | | | | | G1: 12.80 (17.86) (P = NR) | | G2: 1.01 (0.75) (P = NR)
| | | | | | | | | G2: 11.20 (20.74) (P = NR) | | Diff over time (P < 0.001)
| | | | | | | | | Diff over time (P < 0.001) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Laxatives, mean (SD): | Laxatives, mean (SD):
| | | | | | | | G1: 2.10 (4.32) | Post-tx:
| | | | | | | | G2: 2.33 (5.16) | G1: 0.06 (0.25) (P = NR)
| | | | | | | | (P = NS) | G2: 0.10 (0.40) (P = NR)
| | | | | | | | | 3 Mo FU:
| | | | | | | | | G1: 0.93 (3.31) (P = NR)
| | | | | | | | | G2: 0.23 (1.10) (P = NR)
| | | | | | | | | 6 Mo FU:
| | | | | | | | | G1: 1.23 (4.53) (P = NR)
| | | | | | | | | G2: 0.43 (2.19) (P = NR)
| | | | | | | | | Diff over time (P = 0.01)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Overexercise, mean (SD): | Overexercise, mean (SD):
| | | | | | | | G1: 7.90 (10.98) | Post-tx:
| | | | | | | | G2: 8.07 (9.70) | G1: 2.53 (6.31) (P = NR)
| | | | | | | | (P = NS) | G2: 5.10 (8.97) (P = NR)
| | | | | | | | | 3 Mo FU:
| | | | | | | | | G1: 2.37 (7.15) (P = NR)
| | | | | | | | | G2: 3.73 (7.87) (P = NR)
| | | | | | | | | 6 Mo:
| | | | | | | | | G1: 2.47 (9.52) (P = NR)
| | | | | | | | | G2: 3.20 (7.17) (P = NR)
| | | | | | | | | Diff over time (P = 0.002)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE-12 Restraint, mean (SD): | EDE-12 Restraint, mean (SD):
| | | | | | | | G1: 3.97 (1.10) | Post-tx:
| | | | | | | | G2: 3.96 (0.88) | G1: 2.36 (1.78) (P = NR)
| | | | | | | | (P = NS) | G2: 2.65 (1.59) (P = NR)
| | | | | | | | | 3 Mo FU:
| | | | | | | | | G1: 2.37 (1.80) (P = NR)
| | | | | | | | | G2: 2.51 (1.62) (P = NR)
| | | | | | | | | 6 Mo FU:
| | | | | | | | | G1: 2.68 (1.78) (P = NR)
| | | | | | | | | G2: 2.56 (1.66) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE-12 Wt Concern, mean (SD): | EDE-12 Wt Concern, mean (SD):
| | | | | | | | G1: 6.97 (3.65) | Post-tx:
| | | | | | | | G2: 7.60 (3.64) | G1: 5.71 (4.38) (P = NR)
| | | | | | | | (P = NS) | G2: 6.13 (4.50) (P = NR)
| | | | | | | | | 3 Mo FU:
| | | | | | | | | G1: 5.44 (4.50) (P = NR)
| | | | | | | | | G2: 6.18 (4.63) (P = NR)
| | | | | | | | | 6 Mo FU:
| | | | | | | | | G1: 5.67 (4.49) (P = NR)
| | | | | | | | | G2: 6.02 (4.66) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE-12 Shape Concern, mean (SD): | EDE-12 Shape Concern, mean (SD):
| | | | | | | | G1: 6.78 (2.45) | Post -tx:
| | | | | | | | G2: 6.50 (2.65) | G1: 5.08 (2.36) (P = NR)
| | | | | | | | (P = NS) | G2: 5.16 (1.93) (P = NR)
| | | | | | | | | 3 Mo FU:
| | | | | | | | | G1: 4.50 (2.54) (P = NR)
| | | | | | | | | G2: 4.00 (1.97) (P = NR)
| | | | | | | | | 6 Mo FU:
| | | | | | | | | G1: 4.86 (2.87) (P = NR)
| | | | | | | | | G2: 4.50 (1.97) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE-12 total score, mean (SD): | EDE-12 Total score, mean (SD):
| | | | | | | | G1: 5.19 (1.36) | Post-tx:
| | | | | | | | G2: 5.23 (1.26) | G1: 3.73 (2.05) (P = NR)
| | | | | | | | (P = NS) | G2: 3.97 (1.68) (P = NR)
| | | | | | | | | 3 Mo FU:
| | | | | | | | | G1: 3.52 (2.17) (P = NR)
| | | | | | | | | G2: 3.87 (2.34) (P = NR)
| | | | | | | | | 6 Mo FU:
| | | | | | | | | G1: 3.81 (2.21) (P = NR)
| | | | | | | | | G2: 3.74 (1.94) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Abstinence (Post):
| | | | | | | | | G1: 20%
| | | | | | | | | G2: 0%
| | | | | | | | | (P = 0.02)
| | | | | | | | | Abstinence (3 mo):
| | | | | | | | | G1: 16.7%%
| | | | | | | | | G2: 3.3%
| | | | | | | | | (P = NS)
| | | | | | | | | Abstinence (6 mo):
| | | | | | | | | G1: 13.3%
| | | | | | | | | G2: 10%
| | | | | | | | | (P = NS)
| | | | | | | | EDE-12 Drive for Thinness, mean (SD): | EDE-12 Drive for Thinness, mean (SD):
| | | | | | | | G1: 14.37 (4.06) | Post-tx:
| | | | | | | | G2: 14.93 (5.16) | G1: 10.63 (5.58) (P = NR)
| | | | | | | | (P = NS) | G2: 11.20 (6.00) (P = NR)
| | | | | | | | | 3 Mo FU:
| | | | | | | | | G1: 9.90 (6.13) (P = NR)
| | | | | | | | | G2: 10.70 (5.86) (P = NR)
| | | | | | | | | 6 Mo FU:
| | | | | | | | | G1: 9.67 (6.77) (P = NR)
| | | | | | | | | G2: 9.53 (6.54) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE-12 Bulimia, mean (SD): | EDE-12 Bulimia, mean (SD):
| | | | | | | | G1: 13.77 (4.11) | Post-tx:
| | | | | | | | G2: 12.87 (4.49) | G1: 8.07 (6.23) (P = NR)
| | | | | | | | (P = NS) | G2: 8.70 (6.45) (P = NR)
| | | | | | | | | 3 Mo FU:
| | | | | | | | | G1: 8.33 (6.15) (P = NR)
| | | | | | | | | G2: 8.30 (6.60) (P = NR)
| | | | | | | | | 6 Mo FU:
| | | | | | | | | G1: 6.26 (4.45) (P = NR)
| | | | | | | | | G2: 5.33 (4.73) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE-12 Body Dissatisfaction, mean (SD): | EDE-12 Body Dissatisfaction, mean (SD):
| | | | | | | | G1: 18.57 (7.75) | Post-tx:
| | | | | | | | G2: 16.57 (8.42) | G1: 15.87 (8.25) (P = NR)
| | | | | | | | (P = NS) | G2: 14.70 (8.12) (P = NR)
| | | | | | | | | Diff over time (P = 0.001)
| | | | | | | | | 3 Mo Fu:
| | | | | | | | | G1: 15.90 (8.89) (P = NR)
| | | | | | | | | G2: 14.23 (8.03) (P = NR)
| | | | | | | | | 6 Mo FU:
| | | | | | | | | G1: 14.97 (8.99) (P = NR)
| | | | | | | | | G2: 12.43 (7.85) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | 18 wks of tx with 19 tx sessions; individual sessions lasting 50 minutes each. | ANCOVA (controlling for pre tx diffs) but they did not report any significance levels for diffs pre-tx between the 2 groups and they did not state which variables they controlled for. | Score: | Bulimic episodes/mo, mean (SD): | Bulimic episodes/ mo, mean (SD): | Present State Examination (PSE) Global mental state, mean (SD): | PSE Global mental state, mean (SD): | Wt, % matched population mean (SD): | Wt, % of matched population mean (SD):
Cooper and Steere, 1995 | To compare CBT without exposure instructions versus with BT (EXRP) without cognitive restructuring to evaluate the validity of the CBT model of the maintenance of BN. | G1: CBT (cog therapy only; N = 15) | 23.8 (18–33) | DSM III-R criteria for BN, however only patients who were ‘bout purgers’ (Purged right after bingeing) were included. | Phase 1: identical in each group (8 sessions on a twice wkly basis; education, exploring the problem; instituting bx techniques to gain control of eating). | | Fair | G1: 21.9 (12.3) | Post Treatment (after 18 wks): | G1: 17.2 (9.8) | Post tx (after 18 wks): | G1: 98.5 (11.5) | Post-tx (after 18 wks):
Setting: | | G2: BT (EXRP only; N = 16) | Sex: | Exclusion: | Phase 2: G1: 8 wkly sessions followed Fairburn's CBT (Problem solving, cog restructuring; without behavioral instruction or hw for reducing dietary restraint). G2: 8 sessions (first 4 twice per wk for EXRP in session (eating and prevented vomiting; second 4 - wkly sessions and prevented bingeing rather than vomiting). Based on Rosen and Leitenberg (but modified to exclude cog factors). | | Intent to treat: | G2: 30.4 (19.4) | G1: 4.5 (7.6) (P = NR) | G2: 17.9 (6.6) | G1: 10.3 (7.7) (P = NR) | G2: 99.3 (11.0) | G1: 98.8 (8.8) (P = NR)
Outpatient, UK | | Enrollment: | Female: 100% | NR | Phase 3: focused on maintenance as described by Fairburn (3 fortnightly sessions). | | No | (P = NR) | G2: 7.4 (13.9) (P = NR) | (P = NR) | G2: 9.3 (8.3) (P = NR) | (P = NR) | G2: 99.2 (10.5) (P = NR)
Enrollment period: | | - Randomized (N = 31); - Completed (N = 27) | Race/ethnicity: | | | | Blinding: | | Diff over time (P = NR) | | Diff over time (P = NR) | | Diff over time (P = NR)
18 mos, dates not provided | | G1: 13 | NR | | | | N/A | | Diff between groups (P = NS) | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | G2: 14 | Wt, % of matched population mean (range): | | | | Adverse events: | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NR)
| | Drop Outs: | 98.9% (82.7–122.2%) | | | | NR | | FU (12 mos): | | FU (12 mos): | | FU (12 mos):
| | G1: N = 1 | Frequency of bulimic episodes during 4 wks before tx, mean (range): | | | | Funding: | | G1: 3.5 (6.3) (P = NR) | | G1: 8.3 (8.5) (P = NR) | | G1: 97.7 (10.4) (P = NR)
| | G2: N = 1 | 26.3 (6–72) | | | | East Anglia Regional Health Authority | | G2: 16.5 (18.4) (P = NR) | | G2: 12.4 (8.9) (P = NR) | | G2: 99.5 (13.9) (P = NR)
| | Withdrawn (due to severe depression): | Frequency of self-induced vomiting during 4 wks before tx, mean (range): | | | | | | Diff over time (P = NR) | | Diff over time (P = NR) | | Diff over time (P = NR)
| | G1: N = 1 | 58.8 (0–580) | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR) | | (P = NR)
| | G2: N = 1 | Onset of both bulimic episodes and purging, yrs, mean: | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | FU: | 19.6 | | | | | | Abstinence rates, N (%): | MADRS Depression, mean (SD): | MADRS Depression, mean (SD):
| | G1: 12 | Duration of BN symptoms, mos, mean (range): | | | | | | G1: 6 (46%) | G1: 21.5 (7.4) | Post tx (after 18 wks):
| | G2: 13 | 56 (5–180) | | | | | | G2: 7 (50%) | G2: 21.1 (7.7) | G1: 14.0 (9.8) (P = NR)
| | 1 in each group required tx for depression and was not assessed. Both responded poorly to tx. | Duration of purging, mos, mean (range): | | | | | | (P = NS) | (P = NR) | G2: 11.8 (11.5) (P = NR)
| | | 55.5 (4–168) | | | | | | Reduction in freq of bulimic episodes, %: | | Diff over time (P = NR)
| | | | | | | | | G1: 78.0% | | Diff between groups (P = NS)
| | | | | | | | | G2: 78.7% | | Diff between groups in change over time (P = NR)
| | | | | | | | | (P = NS) | | FU (12 mos):
| | | | | | | | | Relapse Rate (Bingeing): | | G1: 8.8 (7.5) (P = NR)
| | | | | | | | | G1: 0/6 who were abstinent | | G2: 14.9 (10.0) (P = NR)
| | | | | | | | | G2: 5/7 who were abstinent | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P < 0.04) | | Diff between groups (P = NR)
| | | | | | | | Self-induced vomiting/mo (SD): | Self-induced vomiting/mo, mean (SD): | | Diff between groups in change over time (P < 0.03)
| | | | | | | | G1: 36.1 (37.8) | Post Treatment (after 18 wks): | | G1 better than G2
| | | | | | | | G2: 79.9 (149.1) | G1: 4.5 (7.9) (P = NR) | BDI, mean (SD): | BDI, mean (SD):
| | | | | | | | (P = NR) | G2: 7.6 (13.2) (P = NR) | G1: 21.8 (8.3) | Post tx (after 18 wks):
| | | | | | | | | Diff over time (P = NR) | G2: 17.9 (11.5) | G1: 10.2 (9.4) (P = NR)
| | | | | | | | | Diff between groups (P = NS) | (P = NR) | G2: 10.4 (12.6) (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Diff over time (P = NR)
| | | | | | | | | FU (12 mos): | | Diff between groups (P = NS)
| | | | | | | | | G1: 4.3 (7.1) (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | | G2: 23.4 (25.8) (P = NR) | | FU (12 mos):
| | | | | | | | | Diff over time (P = NR) | | G1: 8.0 (9.4) (P = NR)
| | | | | | | | | Diff between groups (P = NR) | | G2: 13.0 (10.8) (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.007) | | Diff over time (P = NR)
| | | | | | | | | G1 better than G2 | | Diff between groups (P = NR)
| | | | | | | | | Abstinence rates, N (%): | | Diff between groups in change over time (P < 0.04)
| | | | | | | | | G1: 7 (54%) | | G1 better than G2
| | | | | | | | | G2: 6 (43%) | STAI - State Anxiety, mean (SD): | STAI - State Anxiety, mean (SD):
| | | | | | | | | (P = NS) | G1: 54.2 (8.4) | Post tx (after 18 wks):
| | | | | | | | | Reduction in freq of vomiting, %: | G2: 43.1 (13.0) | G1: 38.8 (10.3) (P = NR)
| | | | | | | | | G1: 82.8% | (P = NR) | G2: 42.3 (15.3) (P = NR)
| | | | | | | | | G2: 91.1% | | Diff over time (P = NR)
| | | | | | | | | (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | Relapse rate (Purging): | | Diff between groups in change over time (P = NS)
| | | | | | | | | G1: 1/7 | | FU (12 mos):
| | | | | | | | | G2: 5/6 | | G1: 41.8 (11.0) (P = NR)
| | | | | | | | | (P = NS) | | G2: 42.0 (12.7) (P = NR)
| | | | | | | | EDE - Dietary restraint, mean (SD): | EDE - Dietary restraint, mean (SD): | | Diff over time (P = NR)
| | | | | | | | G1: 3.4 (1.6) | Post Treatment (after 18 wks): | | Diff between groups (P = NR)
| | | | | | | | G2: 3.2 (1.3) | G1: 1.2 (1.4) (P = NR) | | Diff between groups in change over time (P = NS)
| | | | | | | | (P = NR) | G2: 0.8 (1.2) (P = NR) | STAI - Trait Anxiety, mean (SD): | STAI - Trait Anxiety, mean (SD):
| | | | | | | | | Diff over time (P = NR) | G1: 55.8 (11.0) | Post tx (after 18 wks):
| | | | | | | | | Diff between groups (P = NS) | G2: 52.0 (10.6) | G1: 44.8 (13.9) (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR) | (P = NR) | G2: 44.5 (14.6) (P = NR)
| | | | | | | | | FU (12 mos): | | Diff over time (P = NR)
| | | | | | | | | G1: 1.0 (1.1) (P = NR) | | Diff between groups (P = NR)
| | | | | | | | | G2: 1.6 (1.5) (P = NR) | | Diff between groups in change over time (P = NS)
| | | | | | | | | Diff over time (P = NR) | | FU (12 mos):
| | | | | | | | | Diff between groups (P = NR) | | G1: 44.3 (12.5) (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR) | | G2: 49.3 (13.6) (P = NR)
| | | | | | | | SRQ Dietary restraint, mean (SD): | SRQ Dietary restraint, mean (SD): | | Diff over time (P = NR)
| | | | | | | | G1: 13.6 (4.1) | Post Treatment (after 18 wks): | | Diff between groups (P = NR)
| | | | | | | | G2: 12.8 (4.5) | G1: 11.2 (5.1) (P = NR) | | Diff between groups in change over time (P = NS)
| | | | | | | | (P = NR) | G2: 8.5 (5.4) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | FU (12 mos):
| | | | | | | | | G1: 11.2 (5.5) (P = NR)
| | | | | | | | | G2: 10.7 (4.2) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE Shape concern, mean (SD): | EDE Shape concern, mean (SD):
| | | | | | | | G1: 4.4 (1.2) | Post Treatment (after 18 wks):
| | | | | | | | G2: 4.3 (1.3) | G1: 2.7 (1.8) (P = NR)
| | | | | | | | (P = NR) | G2: 2.2 (1.7) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | FU (12 mos):
| | | | | | | | | G1: 2.6 (1.4) (P = NR)
| | | | | | | | | G2: 3.1 (1.4) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE Wt concern, mean (SD): | EDE Wt concern, mean (SD):
| | | | | | | | G1: 4.4 (1.3) | Post Treatment (after 18 wks):
| | | | | | | | G2: 3.8 (1.8) | G1: 2.6 (1.9) (P= NR)
| | | | | | | | (P = NR) | G2: 1.6 (1.4) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | FU (12 mos):
| | | | | | | | | G1: 2.3 (1.3) (P = NR)
| | | | | | | | | G2: 2.4 (1.6) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Importance of shape and wt (geometric mean of 2 EDE items) (SD): | Importance of shape and wt (geometric mean of 2 EDE items) (SD):
| | | | | | | | G1: 3.4 (1.8) | Post Treatment (after 18 wks):
| | | | | | | | G2: 3.4 (2.3) | G1: 2.7 (1.8) (P= NR)
| | | | | | | | (P = NR) | G2: 1.7 (2.1) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | FU (12 mos):
| | | | | | | | | G1: 2.5 (1.2) (P = NR)
| | | | | | | | | G2: 2.4 (2.0) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EAT, mean (SD): | EAT, mean (SD):
| | | | | | | | G1: 49.7 (16.9) | Post Treatment (after 18 wks):
| | | | | | | | G2: 44.3 (16.6) | G1: 20.0 (14.2) (P = NR)
| | | | | | | | (P = NR) | G2: 17.5 (15.6) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | FU (12 mos):
| | | | | | | | | G1: 18.8 (14.7) (P = NR)
| | | | | | | | | G2: 24.3 (17.1) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | BSQ Body shape dissatisfaction, mean (SD): | BSQ Body shape dissatisfaction, mean (SD):
| | | | | | | | G1: 124.5 (30.9) | Post Treatment (after 18 wks):
| | | | | | | | G2: 120.6 (36.4) | G1: 84.3 (32.8) (P= NR)
| | | | | | | | (P = NR) | G2: 77.9 (36.5) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | FU (12 mos:
| | | | | | | | | G1: 78.5 (26.3) (P = NR)
| | | | | | | | | G2: 89.3 (31.6) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Desired wt, mean (SD): | Desired wt, mean (SD):
| | | | | | | | G1: 87.6 (6.3) | Post Treatment (after 18 wks):
| | | | | | | | G2: 87.1 (4.5) | G1: 92.3 (6.9) (P = NR)
| | | | | | | | (P = NR) | G2: 91.7 (6.6) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | FU (12 mos):
| | | | | | | | | G1: 91.1 (5.8) (P = NR)
| | | | | | | | | G2: 88.8 (8.3) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
Author, year: | Research objective: | Groups (N = 143): | Age, range: | Inclusion: | 12 wk study with 4 tx groups, differing on 2 factors: early abstinence and tx intensity; 2 groups were “high abstinence”, with visits clustered early in tx, 2 were “low abstinence”, where participants were instructed to improve at their own rate.; 2 groups were high intensity (45 program hours), 2 were low intensity (22.5 hrs); factors were crossed to create 4 tx conditions. | Time to tx response: performed separately for 4 tx response definitions using survival analyses; drop-outs and completers who failed to meet tx response criteria were treated as censored observations. | Score: | Initial Response: | Maintained response, by last tx visit:
Crosby, Mitchell et al., 1993 | To reanalyze treatment response and relapse using survival analyses in a 12-wk RCT of group CBT for the tx of BN. | High Abstinence: HA | 18 to 50 | Aged 18 to 50; meeting DSM-IIIR criteria for BN, with additional criteria for frequency at 3/wk for 6 mos prior to evaluation | All participants self-monitored daily eating behavior using the Eating Behaviors III. | Time to relapse after initial response: analyzed in a sub-sample of participants using survival analyses; participants abstinent at tx end were treated as censored observations. | Poor | Total abstinence, no binging, vomiting, or laxative abuse per 2 wks (%): | Total abstinence (%):
Setting: | | High Intensity: HI | Sex: | Exclusion: | | In both analyses, relationships between groups and outcome variables were assessed by parametric accelerated failure time models, fitted using a log logistic distribution. | Intent to treat: | G1: 27 (82%) | G1: 22 (67%) (P =NR)
NR | | Low Abstinence: LA | 100% female | Concomitant alcohol or drug abuse, bipolar disorder or schizophrenia | | | NR | G2: 27 (66%) | G2: 28 (68%) (P =NR)
Enrollment period: | | Low Intensity: LI | Race/ethnicity: | | | | Blinding: | G3: 20 (57%) | G3: 22 (63%) (P =NR)
NR | | G1: HA/HI (N = 33) | NR | | | | NR | G4: 8 (24%) | G4: 7 (21%) (P =NR)
| | G2: HA/ LI (N = 41) | | | | | Adverse events: | Overall: 82 (57%) | Overall: 79 (55%) (P =NR)
| | G3: LA/HI (N = 35) | | | | | NR | (P < 0.001) | Diff between groups (P = NR)
| | G4: LA/LI (N = 34) | | | | | Funding: | G1 sig higher overall | Diff between groups in change over time (P <0.0001)
| | Enrollment: | | | | | NR | G4 sig lower overall | - 74 participants (90% initial; 93% maintained) met total criteria for both response times
| | - 143 enrolled and randomized | | | | | | Near abstinence, 1 or fewer episodes per 2 wks (%): | Near abstinence (%):
| | | | | | | | G1: 28 (85%) | G1: 25 (76%)(P =NR)
| | | | | | | | G2: 34 (83%) | G2: 30 (73%) (P =NR)
| | | | | | | | G3: 24 (69%) | G3: 23 (66%)(P =NR)
| | | | | | | | G4: 16 (47%) | G4: 9 (27%) (P =NR)
| | | | | | | | Overall: 102 (71%) | Overall: 87 (61%) (P =NR)
| | | | | | | | (P < 0.001) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.0001)
| | | | | | | | | - 86 participants (84% initial; 99% maintained) met near criteria for both response times
| | | | | | | | | Survival Analyses:
| | | | | | | | | Time to initial response, total abstinence:
| | | | | | | | | Diff between groups in change over time: X^2^ = 46.9 (P < 0.001)
| | | | | | | | | Diff between G1 and G2 (P = 0.005)
| | | | | | | | | G1 sig shorter than G2
| | | | | | | | | G2/G3 combined sig shorter than G4
| | | | | | | | | Diff between G2 and G3 (P = NS)
| | | | | | | | | Time to initial response, near abstinence:
| | | | | | | | | Diff between groups in change over time:X^2^ = 34.7 (P < 0.001)
| | | | | | | | | Diff between G1 and G2 (P = 0.064)
| | | | | | | | | G2/G3 combined sig shorter than G4;
| | | | | | | | | Diff between G2 and G3 (P = NS)
| | | | | | | | | Relapse after initial response, total abstinence:
| | | | | | | | | In first week, 48% G1 and 25% G3 relapsed;
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Relapse after initial response, near abstinence:
| | | | | | | | | Diff between groups (P <0.001)
| | | | | | | | | Diff between G4 and G1/G2/G3 combined (P < 0.001)
| | | | | | | | | G4 sig higher than combined.
| | | | | | | | | G1 and G3 sig lower than others (P = NR)
| | | | | | | | | Diff between G1 and G3 (P = NS)
| | | | | | | | | Relapse after maintained, total abstinence:
| | | | | | | | | Diff between groups (P < 0001)
| | | | | | | | | Relapse after maintained, near abstinence:
| | | | | | | | | Diff between groups (P < 0001)
| | | | | | | | | Diff between G1 and G2/G3 combined in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Pre-tx Assessment: | To test tx effects on psychopathology: ANCOVAs at post-tx and FU with pre-tx score as covariate (parametric data) or Mann-Whitney or Fischer's exact test for non-parametric data. | Score: | Binge frequency, past 28 days, mean (SD): | Binge frequency, past 28 days, mean (SD): | BDI, mean (SD): | BDI, mean (SD):
Davis et al., 1999 | To investigate the efficacy of stepped care involving brief group PE followed by CBT to treat BN.To study the co-variation between clinical outcome and nonspecific psychopathology. | G1: PE only (N = 32) | 27.1 (5.3) | DSM III-R criteria for BN by clinician or EDE, 85–125% of matched population mean wt, min 6-mo duration of illness | EDE, BDI, BSI, RSE, semistructured interview, Binge Eating Adjective Checklist (BEAQ) | To examine covariation between remission in eating sx and psychopathology: univariate and multivariate ANOVA and paired t-tests. | Poor | G1: 21.2 (12.8) | Post-tx: | G1: 21.3 (9.3) | Post-tx:
Setting: | To determine predictors of best response to stepped care strategy. | G2: PE + CBT (N = 39) | Sex: | Exclusion: | Brief group PE (6, 90-minutes wkly sessions), manualized, focusing on self-care strategies (i.e., self-monitoring, meal planning, cognitive restructuring, stimulus control, and problem-solving) as well as normalizing eating behavior. Initially, 5–8 BN study participants plus 6–16 non-BN clinic patients (EDNOS or AN) per group. Followed by interim assessments. | To predict outcome: discriminant function analysis between nonremitted and remitted PE + CBT. | Intent to treat: | G2: 24.2 (19.7) | G1: 11.5 (19.0) (P < 0.001) | G2R: 18.9 (10.5) | G1: 11.8 (7.3) (P < 0.05)
Eating Disorder Outpatient Clinic of Toronto Hospital, Toronto, Canada | | Analysis presented on 56 completers only | Female: 100% | Current psychological tx (therapy or meds); suicide risk; psychosis; medical instability; previous exposure to one of txs being studied | Randomization (2:1) | | No | | G2: 3.9 (7.4) (P < 0.001) | G2N: 22.1 (9.6) | G2R: 4.2 (4.5) (P < 0.05)
Enrollment period: | | G2R: CBT remitters (N = 16) | Race/ethnicity: | | G1: 16 wks individual CBT (12 sessions if < 4 binge/purge episodes in last 4 wks of mope; 20 session if ge; 4 episodes) | | Blinding: | | Diff between groups (P < 0.03) | | G2N: 16.5 (12.1) (P = NS)
16 mos | | G2N: CBT non-remitters (N = 21) | Caucasian: 100% | | G2: 16 wk no-tx | | No | | Diff between groups in change over time (P = NR) | | Diff between groups (P < 0.05)
| | Enrollment: | Duration of illness, yrs, mean (SD): | | Post-tx and FU assessments | | Adverse events: | | 16 wk FU: | | G2R better than G1 and G2N
| | Referred by physician (71%) | 7.6 (5.4) | | Post-assessment | | None reported | | G1: 8.4 (9.5), vs. post-tx (P = NS) | | Diff between groups in change over time (P = NR)
| | Recruited via newspaper ad (29%) | Education: | | (as above) | | Funding: | | G2: 3.6 (8.2), vs. post-tx (P = NS) | | 16 wk FU:
| | Enrolled (N = 71) | College: 58% | | | | Ontario Ministry of Health | | Diff between groups (P < 0.02) | | G1: 12.9 (7.2), vs. post-tx (P = NS)
| | Completed initial 6 wk group PE and randomized (N = 58) | Employment: | | | | | | Diff between groups in change over time (P = NR) | | G2R: 7.1 (7.7), vs. post-tx (P = NS)
| | G1: 19 | Full-time52% | | | | | Purge frequency, past 28 days, mean (SD): | Purge frequency, past 28 days, mean (SD): | | G2N: 15.6 (12.4), vs. post-tx (P = NS)
| | G2: 39 | Marital status: | | | | | G1: 30.1 (16.6) | Post-tx: | | Diff between groups (P < 0.05)
| | Dropouts, pre-tx: | Single: 78% | | | | | G2: 38.3 (43.1) | G1: 16.7 (21.7) (P < 0.001) | | G2R better than G2N
| | G1: 13 | Hx of past AN: | | | | | | G2: 4.8 (9.0) (P < 0.001) | | Diff between groups in change over time (P = NR)
| | G2: 2 | 34% | | | | | | Diff between groups (P < 0.002) | Brief Symptom Inventory (Global), mean (SD): | Brief Symptom Inventory (Global), mean (SD):
| | Diff between groups in hx, demographics, bingeing, purging, and psychometric measures (P = NS) | Purge type: | | | | | | Diff between groups in change over time (P = NR) | G1: 1.3 (0.6) | Post-tx:
| | Dropouts, during tx: | Vomit: 87% | | | | | | 16 wk FU: | G2R: 1.3 (0.8) | G1: 1.0 (0.5) (P < 0.05)
| | G1: 0 | Laxatives: 34% | | | | | | G1: 12.3 (13.2), vs. post-tx (P = NS) | G2N: 1.5 (0.7) | G2R: 0.4 (0.4) (P < 0.05)
| | G2: 2 | | | | | | | G2: 4.8 (9.6), vs. post-tx (P = NS) | | G2N: 1.2 (0.7) (P = NS)
| | | | | | | | | Diff between groups (P < 0.012) | | Diff between groups (P < 0.05)
| | | | | | | | | Diff between groups in change over time (P = NR) | | G2R better than G1 and G2N
| | | | | | | | EDE-Global, mean (SD): | EDE Global, mean (SD): | | Diff between groups in change over time (P = NR)
| | | | | | | | G1: 3.5 (1.0) | Post-tx: | | 16 wk FU:
| | | | | | | | G2: 3.6 (1.1) | G1: 1.9 (1.1) (P < 0.001) | | G1: 1.0 (0.7), vs. post-tx (P = NS)
| | | | | | | | | G2: 2.1 (1.3) (P < 0.001) | | G2R: 0.6 (0.6), vs. post-tx (P = NS)
| | | | | | | | | Diff between groups (P = NS) | | G2N: 1.2 (0.8), vs. post-tx (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups (P < 0.05)
| | | | | | | | | 16 wk FU: | | G2R better than G2N
| | | | | | | | | G1: 2.2 (1.2), vs. post-tx (P = NS) | | Diff between groups in change over time (P = NR)
| | | | | | | | | G2: 2.0 (1.3), vs. post-tx (P = NS) | Rosenberg Self-esteem (RSE), mean (SD): | Rosenberg Self-esteem (RSE), mean (SD):
| | | | | | | | | Diff between groups (P = NS) | G1: 24.3 (5.4) | Post-tx:
| | | | | | | | | Diff between groups in change over time (P = NR) | G2R: 26.2 (4.8) | G1: 26.5 (5.7) (P < 0.05)
| | | | | | | | | Binge remittance: | G2N: 22.4 (4.3) | G2R: 34.6 (3.3) (P < 0.05)
| | | | | | | | | Post-tx: | | G2N: 24.1 (6.5) (P = NS)
| | | | | | | | | G1: 26.3% | | Diff between groups (P < 0.05)
| | | | | | | | | G2: 51.4% | | G2R better than G1 and G2N
| | | | | | | | | Diff between groups (P = NS) | | Diff between groups in change over time (P = NR)
| | | | | | | | | 16 wk FU: | | 16 wk FU:
| | | | | | | | | G1: 26.3% | | G1: 26.9 (6.54), vs. post-tx (P = NS)
| | | | | | | | | G2: 54.1% | | G2R: 32.5 (4.8), vs. post-tx (P = NS)
| | | | | | | | | Diff between groups (P < 0.04) | | G2N: 24.6 (5.7), vs. post-tx (P = NS)
| | | | | | | | | Purge remittance: | | Diff between groups (P < 0.05)
| | | | | | | | | Post-tx: | | G2R better than G2N
| | | | | | | | | G1: 15.8% | | Diff between groups in change over time (P = NR)
| | | | | | | | | G2: 54.1% | | Outcome, predictor (Wilks's lambda), mean:
| | | | | | | | | (P < 0.006) | | RSE (0.805)
| | | | | | | | | 16 wk FU: | | G2R: 28.0
| | | | | | | | | G1: 21.1% | | G2N: 22.8
| | | | | | | | | G2: 51.4% | | Binge frequency
| | | | | | | | | (P < 0.03) | | (0.691)
| | | | | | | | | Full remittance: | | G2R: 11.1
| | | | | | | | | Post-tx: | | G2N: 18.6
| | | | | | | | | G1: 10.5% | | Binge Eating Adjective Checklist
| | | | | | | | | G2: 43.2% | | (0.583)
| | | | | | | | | (P < 0.02) | | G2R: 2.0
| | | | | | | | | 16 wk FU: | | G2N: 12.1
| | | | | | | | | G1: 15.8% | | Lower self-esteem, more frequent bingeing, and more dramatic shifts away from negative psychological and physical states during an episode of bingeing were sigly more characteristic of non-remitted than remitted, chi-square = 18.0 (P < 0.001)
| | | | | | | | | G2: 37.8%
| | | | | | | | | (P = NS)
| | | | | | | | Binge frequency, past 28 days, mean (SD): | Binge frequency, past 28 days, mean (SD):
| | | | | | | | G2R: 21.5 (16.5) | Post-tx:
| | | | | | | | G2N: 26.1 (22.0) | G2R: 0.0 (NA) (P = NR)
| | | | | | | | | G2N: 6.8 (8.8) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 16 wk FU:
| | | | | | | | | G2R: 0.3 (1.3), vs. post-tx (P = NR)
| | | | | | | | | G2N: 6.2 (10.2), vs. post-tx (P = NR)
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Purge frequency, past 28 days, mean (SD): | Purge frequency, past 28 days, mean (SD):
| | | | | | | | G2R: 26.1 (25.7) | Post-tx:
| | | | | | | | G2N: 42.1 (51.5) | G2R: 0.0 (NA) (P = NR)
| | | | | | | | | G2N: 7.7 (10.4) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 16 wk FU:
| | | | | | | | | G2R: 0.6 (1.5) (P = NR)
| | | | | | | | | G2N: 7.3 (11.6) (P = NR)
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE Global, mean (SD): | EDE Global, mean (SD):
| | | | | | | | G2R: 3.6 (1.1) | Post-tx:
| | | | | | | | G2N: 3.6 (1.1) | G2R: 1.3 (0.8) (P = NR)
| | | | | | | | | G2N: 2.8 (1.2) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 16 wk FU:
| | | | | | | | | G2R: 1.3 (0.9) (P = NR)
| | | | | | | | | G2N: 2.6 (1.3) (P = NR)
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | For entire sample (N = 75), unless otherwise indicated: | Inclusion: | Each tx group involved 19, 40–50 minutes outpatient sessions over 18 wks; for mo 1, sessions conducted 2x/wk, then fortnightly for duration of study. | Two planned comparisons: CBT versus BT, and CBT versus IBT; Power analyses performed (assessing 20 persons per tx group); data inspected to assess whether transformation required for parametric testing; variables with skewed distribution were subject to log transformations; one-way ANOVA assessed pre-tx diffs; Tx effects assessed using 3 x 2, repeated measures ANOVA; diff effects between groups were assessed by ANCOVA with pre-tx values as the covariate; alpha was set at < 0.05, t-tests used for planned comparisons between groups. | Score: | Unless otherwise specified, N = 60 | | SCL-90 Global severity index (GSI), mean (95% CI): | End-of-tx: | BMI, kg/m^2^, mean (95% CI): | End-of-tx:
Fairburn et al., 1991 | To assess the efficacy of CBT versus a simplified behavioral version of CBT in the tx of 75 women with BN | G1: CBT (N = 25) | Age, yrs, mean (95% CI): | For prior 6 mos, met criteria for BN (DSM IIII-R); aged 17 yrs or older; BMI > 17 | CBT occurred in 3 stages: wks 1–4 focused on behaviorally enhancing control over eating, including self-monitoring; wks 5–12 cognitively focused; wks 13–18 maintenance of progress following end of tx. | | Fair | *Geometric means (N = 43 and N = 19 for vomiting and laxative use, respectively). | | G1: 1.35 (1.04–1.65) | SCL-90 GSI, mean (95% CI): | G1: 22.4 (20.8–23.9) | BMI, kg/m^2^, mean (95% CI):
Companion articles: | To assess the efficacy of CBT versus IPT in the tx of women with BN. | G2: BT (N = 25) | 24.2 (22.8–25.6) | Exclusion: | BT tx focused exclusively on the normalization of eating habits, including self-monitoring. | | Intent to treat: | Objective Bulimic Episodes, per 28 days*, mean (95% CI): | End-of-tx: | G2: 1.26 (0.90-1.62) | G1: 0.59 (0.33–0.85) (P = NR) | G2: 22.6 (21.0–24.2) | G1: 23.3 (21.3–25.2) (P = NR)
Fairburn, Jones et al., 1993 | | G3: IPT (N = 25) | Sex: | Patients with concurrent AN | IPT used manual developed by Klerman et al. (1984), diverging from protocol only in the first phase of tx--focusing on the ED (rather than depression.) | | No | G1: 18.1 (12.2–26.5) | Objective Bulimic Episodes, per 28 days*, mean (95% CI): | G3: 1.33 (1.08–1.59) | G2: 0.76 (0.41–1.12) (P = NR) | G3: 22.2 (21.1–23.3) | G2: 23.0 (21.3–24.7) (P = NR)
Fairburn, Peveler et al., 1993 | | Enrollment: | Female: 100% | | At baseline at end-of tx, eating-specific issues, global fx, and depression were assessed using the EDE, EAT, SCL-90, and BDI. | | Blinding: | G2: 14.9 (9.6–22.7) | G1: 0.6 (0.1–1.4) (P = NR) | (P = NS) | G3: 0.70 (0.46–0.94) (P = NR) | (P = NS) | G3: 22.2 (20.7–23.7) (P = NR)
Setting: | | - 126 individuals referred from physicians for a study on tx of BN offered screening appts; - 117 (85%) screened; - 83 met study criteria; - 3 excluded due to major psychiatric condition; 2 excluded due to unavailability; 3 failed attendance to entry; - 75 enrolled and randomized; - 66 (88%) met full DSM III-R criteria for BN; 9 met all criteria save severity of attitudinal disturbance; - 13 (17%) discontinued tx: 4 from G1 (16%); 6 from G2 (24%); 3 from G3 (12%); 2 others withdrew (1 from G2; 1 from G3); - 60 completed | Race/ethnicity: | | | | NA | G3: 16.4 (12.1–22.2) | G2: 1.3 (0.3–3.4) (P = NR) | | Diff over time (P < 0.05) | | Diff over time (P = 0.02)
Outpatient Clinic; Recruited from county of Oxfordshire, UK | | | NR | | | | Adverse events: | (P = NS) | G3: 1.8 (0.4–4.3) (P = NR) | | (P = NR) | | Diff between groups (P = NS)
Enrollment period: | | | Vomiting frequency, days/mo, mean (CI) (N = 56): | | | | “Limited motivation to change” was the most common reason for attrition; 1 participant (G2) dropped out due to severe wt loss | | Diff over time (P < 0.05) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
NR | | | 28.9 (23.2–34.7) | | | | Funding: | | Diff between groups (P = NS) | BDI, mean (95% CI): | BDI, mean (95% CI):
| | | Practiced by 72% of sample | | | | Welcome Trust, London, Eng; personal support for authors from lectureships/fellowships | | Diff between groups in change over time (P = NS) | G1: 24.1 (20.1–28.1) | G1: 10.1 (5.3–15.0) (P = NR)
| | | Laxative frequency, days/ mo, mean (CI) (N = 26): | | | | | | - Mean overall geometric frequency changed from 16.5 to 1.2 at end-of-tx: a 95% reduction; - Similarly for subjective BE, no diff between groups (P = NS) or for both types combined (P = NS) | G2: 22.3 (16.5–28.1) | G2: 13.6 (7.6–19.5) (P = NR)
| | | 14.7 (8.9–20.4) | | | | | | Abstinence (no bulimic episodes), N (%): | G3: 24.3 (18.6–30.0) | G3: 12.5 (7.6–17.4) (P = NR)
| | | Duration of BN, yrs, mean (CI): | | | | | | G1: 15/21 (71%) (P = NR) | (P = NS) | Diff over time (P < 0.05)
| | | 4.4 (3.4–5.3) | | | | | | G2: 11/18 (62%) (P = NR) | | (P = NR)
| | | Current BMI, kg/m^2^, mean (CI): | | | | | | G3: 13/21 (62%) (P = NR) | | Diff between groups in change over time (P = NS)
| | | 22.2 (21.5–23.0) | | | | | | Diff between group (P = NS)
| | | Current BMI classification, N (%): | | | | | EDE-Dietary Restraint, mean (95% CI): | EDE-Dietary Restraint, mean (95% CI):
| | | Underwt: 11 (18%) | | | | | G1: 3.7 (3.1–4.3) | G1: 1.3 (0.7–1.9) (P = NR)
| | | Normal wt: 42 (70%) | | | | | G2: 3.3 (2.6–4.0) | G2: 2.3 (1.6–3.0) (P = NR)
| | | Overwt: 4 (7%) | | | | | G3: 3.3 (2.9–3.7) | G3: 2.1 (1.5–2.7) (P = NR)
| | | Obese: 3 (5%) | | | | | (P = NS) | Diff over time (P < 0.05)
| | | Highest BMI since menarche, kg/m^2^, mean (CI): | | | | | | Diff between groups (P = 0.05)
| | | 25.3 (24.4–26.3) | | | | | | Diff between groups in change over time
| | | Lowest BMI since menarche, kg/m^2^, mean (CI): | | | | | | G1 better than G2 (P = 0.05)
| | | 18.3 (17.6–18.9) | | | | | | G1 better than G3 (P = 0.02)
| | | EAT score, mean (CI): | | | | | Self-induced vomiting, per 28 days, mean (95% CI): | Self-induced vomiting, per 28 days, mean (95% CI):
| | | 48.2 (44.3–52.0) | | | | | G1: 28.5 (18.1–44.6) | G1: 1.5 (0.5–3.1) (P = NR)
| | | SCL-90 Global Severity Index (GSI) score, mean (CI): | | | | | G2: 18.5 (10.1–33.3) | G2: 0.9 (0–2.9) (P = NR)
| | | 1.4 (1.2–1.5) | | | | | G3: 16.4 (9.9–26.6) | G3: 5.5 (1.6–14.9) (P = NR)
| | | BDI, mean (CI): | | | | | (P = NS) | Diff over time (P < 0.05)
| | | 24.0 (21.4–26.6) | | | | | | Diff between groups (P = 0.03)
| | | Of entire sample, 56% practiced vomiting, 35% used laxatives; 12% used neither | | | | | | Diff between groups in change over time
| | | | | | | | | G1 vs. G2 (P = NS)
| | | | | | | | | G1 better than G3 (P = 0.03)
| | | | | | | | Laxative misuse, per 28 days, mean (95% CI): | Laxative misuse, per 28 days, mean (95% CI) (N = 19):
| | | | | | | | G1: 4.7 (1.4–12.6) | G1: 0.3 (0–1.6) (P = NR)
| | | | | | | | G2: 13.1 (3.9–39.4) | G2: 1.4 (0–8.1) (P = NR)
| | | | | | | | G3: 13.7 (6.4–28.2) | G3: 2.3 (0–15.5) (P = NR)
| | | | | | | | (P = NS) | Diff over time (P < 0.05)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Unless otherwise specified, N = 60
| | | | | | | | *Geometric means (N = 43 and N = 19 for vomiting and laxative use, respectively).
| | | | | | | | EDE-Attitudes to shape, mean (95% CI): | End-of-tx:
| | | | | | | | G1: 4.1 (3.6–4.7) | EDE-Attitudes to shape, mean (95% CI):
| | | | | | | | G2: 4.0 (3.4–4.7) | G1: 2.1 (1.5–2.6) (P = NR)
| | | | | | | | G3: 3.6 (3.0–4.2) | G2: 3.3 (2.5–4.0) (P = NR)
| | | | | | | | (P = NS) | G3: 2.6 (2.1–3.2) (P = NR)
| | | | | | | | | Diff over time (P < 0.05)
| | | | | | | | | Diff between groups (P = 0.01)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G1 better than G2 (P = 0.003)
| | | | | | | | | G1 vs. G3 (P = NS)
| | | | | | | | EDE-Attitudes to wt, mean (95% CI): | EDE-Attitudes to wt, mean (95% CI):
| | | | | | | | G1: 4.3 (3.7–4.8) | G1: 1.7 (1.1–2.2) (P = NR)
| | | | | | | | G2: 3.8 (3.2–4.5) | G2: 2.9 (2.2–3.6) (P = NR)
| | | | | | | | G3: 3.7 (2.9–4.4) | G3: 2.4 (1.9–2.9) (P = NR)
| | | | | | | | (P = NS) | Diff over time (P < 0.05)
| | | | | | | | | Diff between groups (P = 0.01)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G1 better than G2 (P = 0.002)
| | | | | | | | | G1 better than G3 (P = 0.04)
| | | | | | | | EAT scores, mean (95% CI): | EAT scores, mean (95% CI):
| | | | | | | | G1: 45.4 (38.9–51.9) | G1: 15.5 (9.2–21.8) (P = NR)
| | | | | | | | G2: 50.2 (43.7–56.7) | G2: 27.8 (19.4–36.3) (P = NR)
| | | | | | | | G3: 46.1 (38.8–53.5) | G3: 29.0 (19.8–38.2) (P = NR)
| | | | | | | | (P = NS) | Diff over time (P < 0.05)
| | | | | | | | | Diff between groups (P = 0.02)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | G1 better than G2 (P = 0.05)
| | | | | | | | | G1 better than G3 (P = 0.01)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (95% CI): | Inclusion: | Assessments reported in Fairburn, Jones et al., 1991 were further measured at 4-, 8- and 12-mo FU. | Proportion of participants who had ceased overeating and self-induced vomiting or laxative use were compared across tx; a 2 x 4 ANCOVA was completed for each outcome variable | Score: | | *Geometric means (N = 37 for objective BE; N = 25 and N = 10 for vomiting and laxative misuse, respectively) | SCL-90 GSI, mean (95% CI): | SCL-90 GSI, mean (95% CI): | BMI, kg/m^2^, mean (95% CI): | BMI, kg/m^2^, mean (95% CI):
Fairburn, Jones et al., 1993 | To assess the efficacy of CBT versus IPT in the tx of women with BN at 4, 8, and 12-mo FU. | G1: CBT (N = 20) | 24.2 (22.8–25.6) | For prior 6 mos, met criteria for BN (DSM IIII-R); aged 17 yrs or older; BMI > 17 | | | Fair | Objective Bulimic Episodes, per 28 days, mean (95% CI): | Objective Bulimic Episodes, per 28 days, mean (95% CI): | G1: 1.38 (1.06–1.70) | 4-mo FU: | G1: 22.5 (20.8–24.1) (P = NR) | 4-mo FU:
Companion articles: | | G3: IPT (N = 17) | Sex: | Exclusion: | | | Intent to treat: | G1: 18.5 (12.2–27.8) | 4-mo FU: | G3: 1.31 (0.99–1.63) | G1: 0.52 (0.29–0.75) (P = NR) | G3: 22.5 (21.3–23.8) (P = NR) | G1: 23.3 (20.9–25.7) (P = NR)
Fairburn et al., 1991 | | Enrollment: | Female: 100% | Patients with concurrent AN | | | No | G3: 17.2 (12.5–23.5) | G1: 0.4 (-0.05–1.2) (P = NR) | End of tx: | G3: 0.49 (0.22–0.76) (P = NR) | End of tx: | G3: 22.4 21.2–23.6) (P = NR)
Fairburn, Peveler et al., 1993 | | - During FU, 7/60 patients who completed tx were withdrawn (G1:1; G2: 3; G3: 3); 3 dropped out (G2: 2; G3: 1); - 25 (33%) of original 75 participants either dropped out or were withdrawn; G1: 8 (32 %); G2: 12 (48%); G3: 8 (32%); - Diff between G1 and G2 (P = 0.04); diff between G1 and G3 (P = 0.33) | Race/ethnicity: | | | | Blinding: | (P = NS) | G3: 0.9 (-0.05–2.8) (P = NR) | G1: 0.61 (0.34–0.88) | 8-mo FU: | G1: 23.4 (21.4–25.5) (P = NR) | 8-mo FU:
Setting: | | | NR | | | | No | End of tx: | 8-mo FU: | G3: 0.60 (0.34–0.86) | G1: 0.45 (0.22–0.68) (P = NR) | G3: 22.6 (21.0–24.2) (P = NR) | G1: 23.1 (21.1–25.1) (P = NR)
Outpatient Clinic; Recruited from county of Oxfordshire, UK | | | | | | | Adverse events: | G1: 0.5 (0.02–1.1) (P = NR) | G1: 0.4 (-.03–1.7) (P = NR) | | G3: 0.45 (0.22–0.68) (P = NR) | | G3: 22.1 (20.6–23.5) (P = NR)
Enrollment period: | | | | | | | 7 participants were withdrawn during FU due to coexisting severe depressive features (N = 3), or BN sx too severe to withhold tx. | G3: 1.5 (0.1–4.5) (P = NR) | G3: 1.1 (0.1–3.2) (P = NR) | | 12-mo FU: | | 12-mo FU:
NR | | | | | | | Funding: | | 12-mo FU: | | G1: 0.46 (0.16–0.76) (P = NR) | | G1: 22.2 (20.9–23.5) (P = NR)
| | | | | | | Project grant from the Welcome Trust, London, Eng; personal support for authors from lectureships/ fellowships | | G1: 0.8 (.02–1.6) (P = NR) | | G3: 0.46 (0.21–0.69) (P = NR) | | G3: 21.6 (20.4–22.8) (P = NR)
| | | | | | | | | G3: 1.1 (0.01–3.2) (P = NR) | | Diff over time (P = NR) | | Diff over time (P < 0.0005)
| | | | | | | | | Diff over time (P = NR) | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups (P = NR) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS) | BDI, mean (95% CI): | BDI, mean (95% CI):
| | | | | | | | | Mean overall geometric frequency was 0.9 at 12-mo FU: a 95% reduction from baseline | G1: 24.1 (19.8–28.3) | 4-mo FU:
| | | | | | | | | Similarly for subjective BE, no diff between groups (P = NS) or for both types combined (P = NS) | G3: 24.7 (17.8–31.6) | G1: 7.5 (3.1–11.9) (P = NR)
| | | | | | | | EDE-Dietary Restraint, mean (95% CI): | EDE-Dietary Restraint, mean (95% CI): | End of tx: | G3: 8.8 (2.6–15.1) (P = NR)
| | | | | | | | G1: 3.7 (3.1–4.3) | 4-mo FU: | G1: 10.3 (5.1–15.4) | 8-mo FU:
| | | | | | | | G3: 3.2 (2.8–3.7) | G1: 1.3 (0.5–2.0) (P = NR) | G3: 11.7 (6.5–17.0) | G1: 6.0 (2.6–9.4) (P = NR)
| | | | | | | | (P = NS) | G3: 1.4 (0.8–2.1) (P = NR) | | G3: 9.7 (3.5–15.9) (P = NR)
| | | | | | | | End of tx: | 8-mo FU: | | 12-mo FU:
| | | | | | | | G1: 1.3 (0.7–1.9) (P = NR) | G1: 1.1 (0.5–1.8) (P = NR) | | G1: 8.3 (2.3–14.2) (P = NR)
| | | | | | | | G3: 1.9 (1.2–2.6) (P = NR) | G3: 1.8 (1.1–2.5) (P = NR) | | G3: 7.7 (2.9–12.5) (P = NR)
| | | | | | | | | 12-mo FU: | | Diff over time (P = NR)
| | | | | | | | | G1: 1.3 (0.7–2.0) (P = NR) | | Diff between groups (P = NR)
| | | | | | | | | G3: 1.7 (1.0–2.5) (P = NR) | | Diff between groups in change over time (P = NS)
| | | | | | | | | Diff over time (P = NR) | RSE, mean (95% CI): | RSE, mean (95% CI):
| | | | | | | | | Diff between groups (P = NR) | G1: 20.8 (19.0–22.5) | 4-mo FU:
| | | | | | | | | Diff between groups in change over time (P = NS) | G3: 21.3 (19.3–23.3) | G1: 27.4 (23.9–30.8) (P = NR)
| | | | | | | | Self-induced vomiting, per 28 days, mean (95% CI): | Self-induced vomiting, per 28 days, mean (95% CI): | End of tx: | G3: 28.0 (24.3–31.7) (P = NR)
| | | | | | | | G1: 30.6 (19.5–48.2) | 4-mo FU: | G1: 27.1 (23.6–30.5) | 8-mo FU:
| | | | | | | | G3: 18.1 (9.9–32.1) | G1: 1.0 (0.02–2.9) (P = NR) | G3: 25.2 (22.8–27.7) | G1: 29.2 (26.2–32.2) (P = NR)
| | | | | | | | (P = 0.03) | G3: 3.4 (0.3–13.5) (P = NR) | | G3: 28.0 (23.9–32.1) (P = NR)
| | | | | | | | End of tx: | 8-mo FU: | | 12-mo FU:
| | | | | | | | G1: 1.3 (0.4–2.9) (P = NR) | G1: 1.2 (0.3–3.0) (P = NR) | | G1: 28.9 (25.6–32.1) (P = NR)
| | | | | | | | G3: 3.6 (0.5–12.8) (P = NR) | G3: 2.9 (0.2–11.3) (P = NR) | | G3: 27.0 (22.6–31.4) (P = NR)
| | | | | | | | | 12-mo FU: | | Diff over time (P < 0.0005)
| | | | | | | | | G1: 2.0 (0.6–4.5) (P = NR) | | Diff between groups (P = NS)
| | | | | | | | | G3: 2.4 (-0.04–11.0) (P = NR) | | Diff between groups in change over time (P = NS)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Mean overall geometric frequency was 2.14 at 12-mo FU: a 90.9% reduction from baseline
| | | | | | | | | *Geometric means (N = 37 for objective BE; N = 25 and N = 10 for vomiting and laxative misuse, respectively)
| | | | | | | | Laxative misuse, per 28 days, mean (95% CI): | Laxative misuse, per 28 days, mean (95% CI) (N = 19):
| | | | | | | | G1: 4.6 (1.4–12.2) | End of tx:
| | | | | | | | G3: 16.8 (5.3–49.1) | G1: 0.3 (-0.3–1.5) (P = NR)
| | | | | | | | (P = NS) | G3: 1.6 (-0.8–30.1) (P = NR)
| | | | | | | | | 4-mo FU:
| | | | | | | | | G1: 0.3 (-0.1–1.8) (P = NR)
| | | | | | | | | G3: 1.5 (-0.8–32.1) (P = NR)
| | | | | | | | | 8-mo FU:
| | | | | | | | | G1: 0.4 (-0.4–2.3) (P = NR)
| | | | | | | | | G3: 1.0 (-0.7–12.8) (P = NR)
| | | | | | | | | 12-mo FU:
| | | | | | | | | G1: 0.9 (-0.4–4.3) (P = NR)
| | | | | | | | | G3: 0.8 (-0.7–7.9) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Sample too small to assess
| | | | | | | | EDE-Attitudes to shape, mean (95% CI): | EDE-Attitudes to shape, mean (95% CI):
| | | | | | | | G1: 4.2 (3.6–4.8) | End of tx:
| | | | | | | | G3: 3.7 (3.0–4.4) | G1: 2.1 (1.5–2.7) (P = NR)
| | | | | | | | (P = NS) | G3: 2.5 (1.9–3.1) (P = NR)
| | | | | | | | | 4-mo FU:
| | | | | | | | | G1: 2.1 (1.5–2.6) (P = NR)
| | | | | | | | | G3: 2.1 (1.3–2.8) (P = NR)
| | | | | | | | | 8-mo FU:
| | | | | | | | | G1: 1.9 (1.2–2.6) (P = NR)
| | | | | | | | | G3: 1.9 (1.3–2.6) (P = NR)
| | | | | | | | | 12-mo FU:
| | | | | | | | | G1: 1.9 (1.3–2.4) (P = NR)
| | | | | | | | | G3: 1.7 (1.0–2.4) (P = NR)
| | | | | | | | | Diff over time (P = 0.007)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE-Attitudes to wt, mean (95% CI): | EDE-Attitudes to wt, mean (95% CI):
| | | | | | | | G1: 4.3 (3.7–4.9) | End of tx:
| | | | | | | | G3: 3.8 (3.0–4.6) | G1: 1.7 (1.1–2.3) (P = NR)
| | | | | | | | (P = NS) | G3: 2.3 (1.7–2.9) (P = NR)
| | | | | | | | | 4-mo FU:
| | | | | | | | | G1: 1.7 (1.1–2.4) (P = NR)
| | | | | | | | | G3: 2.0 (1.3–2.7) (P = NR)
| | | | | | | | | 8-mo FU:
| | | | | | | | | G1: 1.8 (1.2–2.4) (P = NR)
| | | | | | | | | G3: 2.1 (1.4–2.7) (P = NR)
| | | | | | | | | 12-mo FU:
| | | | | | | | | G1: 1.8 (1.2–2.4) (P = NR)
| | | | | | | | | G3: 1.8 (1.1–2.5) (P = NR)
| | | | | | | | | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EAT scores, mean (95% CI): | EAT scores (N = 37), mean (95% CI):
| | | | | | | | G1: 45.7 (38.8–52.5) | End of tx:
| | | | | | | | G3: 45.2 (36.5–53.9) | G1: 15.4 (8.7–22.1) (P = NR)
| | | | | | | | (P = NS) | G3: 27.6 (17.0–38.2) (P = NR)
| | | | | | | | | 4-mo FU:
| | | | | | | | | G1: 16.5 (9.2–23.8) (P = NR)
| | | | | | | | | G3: 18.7 (10.4–26.9) (P = NR)
| | | | | | | | | 8-mo FU:
| | | | | | | | | G1: 14.5 (9.1–19.8) (P = NR)
| | | | | | | | | G3: 20.3 (11.3–29.3) (P = NR)
| | | | | | | | | 12-mo FU:
| | | | | | | | | G1: 16.3 (7.9–24.7) (P = NR)
| | | | | | | | | G3: 20.4 (9.9–30.8) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Abstinence, ceasing to have episodes of uncontrolled overeating (both objective and subjective), and ceasing to take laxatives and vomit:
| | | | | | | | | 12-mo FU:
| | | | | | | | | G1: 36% (N = 9/25)
| | | | | | | | | G2: 20% (N = 5/20)
| | | | | | | | | G3: 44% (N = 11/25)
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G1 better than G2, odds ratio (CI): 2.49 (1.34–4.62) (P = 0.05)
| | | | | | | | | G1 vs. G3 (P = NS)
Author, year: | Research objective: | Groups: | N = 75 unless otherwise indicated. | Inclusion: | Each tx group involved 19, 40–50 minutes outpatient sessions over 18 wks; For mo 1, sessions conducted 2x/wk, then fortnightly for duration of study. | Based on prior research, pre-tx predictor variables selected for use in regression modeling. They included: ED duration, ED age of onset, hx of AN, objective binge frequency, dietary restraint severity, attitude disturbance (sum of EDE shape and wt concerns), ED psychopathology severity (sum of 5 EDE scales), SCL-90 GSI severity, self-esteem, personality disturbance. | Score: | No sig group diffs in objective binge episodes, dietary restraint, vomiting frequency, laxative misuse. | All analyses based on data from 50 patients who remained in the study to the end of FU. | No sig group diffs global severity index or BDI.
Fairburn, Peveler et al., 1993 | To assess predictors of 12-month outcome in patients who received short-term psychological tx for BN; also to test the specific hypothesis that high attitudinal disturbance predicts poorer outcome in patients who initially respond to short-term tx. | G1: CBT (N = 25) | Age, yrs, mean (95% CI): | For prior 6 mos, met criteria for BN (DSM IIII-R); aged 17 yrs or older; BMI > 17 | CBT occurred in 3 stages: wks 1–4, focused on behaviorally enhancing control over eating, including self-monitoring; wks 5–12, cognitively focused; wks 13–18, maintenance of progress following end of tx. | Linear regression to predict the continuous Outcome Index (overall severity of ED psychopathology); logistic regression to predict 2 categorical outcome indexes (1: decline in ED psychopathology within 1 SD of mean of comparison sample, yes/no; 2: cessation of objective and subjective bingeing, vomiting, and laxative use, yes/no). | Fair | | Relation between degree of pre-tx attitudinal disturbance and three indexes of outcome:
Companion articles: | | G2: BT (N = 25) | 24.2 (22.8–25.6) | Exclusion: | BT tx focused exclusively on the normalization of eating habits, including self-monitoring. | | Intent to treat: | | Outcome 1: Global EDE, mean (SD): 1.40 (1.03)
Fairburn et al., 1991 | | G3: IPT (N = 25) | Sex: | Patients with concurrent AN | IPT used manual developed by Klerman et al. (1984), diverging from protocol only in the first phase of tx, focusing on ED (rather than depression.) | | No | | Degree of Attitudinal disturbance at pretreatment:
Fairburn, Jones et al., 1993 | | Enrollment: | Female: 100% | | At baseline at end-of tx, eating-specific issues, global fx, and depression were assessed using EDE, EAT, SCL-90, and BDI. | | Blinding: | | Low 0 – 7 (N = 12): 1.55 (1.15)
Setting: | | - 126 individuals referred from physicians for a study on tx of BN offered screening appointments; - 117 (85%) screened; - 83 met study criteria; - 3 excluded due to major psychiatric condition; 2 excluded due to unavailability; 3 failed attendance to entry; - 75 enrolled and randomized; - 66 (88%) met full DSM III-R criteria for BN; 9 met all criteria except severity of attitudinal disturbance; - 60 (80%) completed tx:; - G1: N = 21 (84%); - G2: N = 18 (72%); - G3: N = 21 (84%); - 50 (67%) completed FU; - On the Personality Diagnostic Questionnaire, non-completers had higher score (56.6 ±15.6) compared to completers (46.1 ± 17.1) (P = 0.02) | Race/ethnicity: | | Patients judged not to need immediate further tx entered into closed 1-yr FU. | | NA | | Moderate 8 – 10 (N = 20): 1.76 (1.10)
Outpatient Clinic; Recruited from county of Oxfordshire, England | | | NR | | | | Adverse events: | | Severe 11 – 12 (N = 18): 0.93 (0.70)
Enrollment period: | | | Vomiting frequency, days/mo, mean (CI) | | | | NA | | Diff between groups (P < 0.05)
NR | | | (N = 56): | | | | Funding: | | Moderate did worst, most severe did best.
| | | 28.9 (23.2–34.7) | | | | Welcome Trust | | Outcome 2: Eating disorder psychopathology within 1 SD of mean for same age women, N (%): 32 (64%):
| | | Laxative frequency, days/ mo, mean (CI) (N = 26): | | | | | | Degree of Attitudinal disturbance at pretreatment:
| | | 14.7 (8.9–20.4) | | | | | | Low (0 – 7) (N = 12): 8 (67%)
| | | Duration of BN, yrs, mean (CI): | | | | | | Moderate (8 – 10) (N = 20): 9 (45%)
| | | 4.4 (3.4–5.3) | | | | | | Severe (11 – 12) (N = 18): 15 (83%)
| | | Current BMI, kg/m^2^, mean (CI): | | | | | | Diff between groups (P < 0.05)
| | | 22.2 (21.5–23.0) | | | | | | Intermediate did worst, most severe did best.
| | | Highest BMI since menarche, kg/m^2^, mean (CI): | | | | | | Relative Risk (95% CI) for Outcome 2:
| | | 25.3 (24.4–26.3) | | | | | | Degree of Attitudinal disturbance:
| | | Lowest BMI since menarche, kg/m^2^, mean (CI): | | | | | | Moderate (8 – 10): 1.22 (0.22 – 6.82)
| | | 18.3 (17.6–18.9) | | | | | | Severe (11 – 12): 0.10 (0.01 – 1.11)
| | | EAT score, mean (CI): | | | | | | Outcome 3: Met strict criteria for good behavioral outcome (ceased episodes of uncontrolled eating, vomiting, laxative use), N (%): 22 (44%):
| | | 48.2 (44.3–52.0) | | | | | | Degree of Attitudinal disturbance at pretreatment:
| | | SCL-90 GSI, mean (CI): | | | | | | Low (0 – 7) (N = 12): 5 (42%)
| | | 1.4 (1.2–1.5) | | | | | | Moderate (8 – 10) (N = 20): 5 (25%)
| | | BDI, mean (CI): | | | | | | Severe (11 – 12) (N = 18): 12 (67%)
| | | 24.0 (21.4–26.6) | | | | | | Diff between groups (P < 0.05)
| | | Practiced vomiting: | | | | | | Intermediate did worst, most severe did best.
| | | 56% | | | | | | RR (95% CI) for Outcome 3:
| | | Used laxatives: | | | | | | Degree of Attitudinal disturbance:
| | | 35% | | | | | | Moderate (8 – 10): 1.32 (0.25 – 7.17)
| | | Did neither: | | | | | | Severe (11 – 12): 0.15 (0.02 – 1.25)
| | | 12% | | | | | | Relapse at FU (no longer meeting Outcome 3), N (%):
| | | | | | | | | Degree of Attitudinal disturbance:
| | | | | | | | | Low (0 – 7): 1/11 (9%)
| | | | | | | | | Moderate (8 – 10): 2/7 (29%)
| | | | | | | | | Severe (11 – 12): 3/4 (75%)
| | | | | | | | | RR (95% CI) relapse after adjusting for tx type:
| | | | | | | | | Degree of attitudinal disturbance:
| | | | | | | | | Moderate (8 – 10): 3.4 (0.2 – 54.1)
| | | | | | | | | Severe (11 – 12): 45.2 (0.9 – 1,339.0)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | 19, 45 to 60 minutes individual sessions delivered over 18 wks. Sessions occurred twice a wk during first mo, once a wk for the next 2 mo, and once every other wk for the final 6 wks. | Repeated measures ANOVA. ANCOVA (Pre-tx scores as covariates). | Score: | | **For all outcome variables diff over time reported to be sig in text. | BDI, mean (SD): | BDI, mean (SD): | Wt (% matched population mean wt), mean (SD): | Wt gain, lb, mean:
Garner et al., 1993 | To compare CBT and brief psychodynamic (“supportive-expressive”) therapy, both delivered in an individual format, according to specific guidelines, and by experienced therapists. | G1: CBT (N = 30) | G1: 23.7 (4.4) | Russell criteria for BN and DSM III-R criteria with the exception that a min avg of 2 binges a wk involving “large” amounts of food was not required; min of 2 episodes of vomiting a wk for the past mo, min duration of illness of 1 yr; present body wt of 85% to 120% MPMW; 18 to 35 yrs old | G1: followed Fairburn's (1985) CBT manual | | Fair | Binge episodes, past 28 days, mean (SD): | Binge episodes, past 28 days, mean (SD): | G1: 16.8 (9.9) | G1: 7.5 (10.6) (P = NR) | G1: 95.3 (9.8) | G1: 6.6 (100.4% MPMW, P = NR)
Setting: | | G2: Supportive-Expressive (N = 30) | G2: 24.6 (4.0) | Exclusion: | G2: Followed Luborsky's (1984) manual, supplemented by psychodynamic writings on ED. Nondirective and emphasized listening to patient and helping identify problems and solutions. | | Intent to treat: | G1: 26.3 (30.2) | G1: 7.1 (14.1) | G2: 18.7 (9.4) | G2: 13.4 (9.5) (P = NR) | G2: 94.9 (7.9) | G2: 3.0 (97.6% MPMW, P = NR)
Outpatient | | Enrollment: | (P = NS) | Current tx for BN | | | No | G2: 31.1 (20.3) | G2: 9.6 (11.0) | (P = NS) | Diff over time (P = NR) | (P = NS) | Diff over time (P < 0.0001)
Toronto, Canada | | Referred to study and screened (N = 92) | Sex: | | | | Blinding: | (P = NS) | Diff between groups (P = NR) | | Diff between groups (P = NR) | | Diff between groups (P = NR)
Enrollment period: | | Met inclusion criteria and enrolled (N = 60) | Female: 100% | | | | NA | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = 0.05) | | Diff between groups in change over time (P = NS)
NR | | Stratified by: | Race/ethnicity: | | | | Adverse events: | Vomiting episodes, past 28 days, mean (SD): | Vomiting episodes, past 28 days, mean (SD): | | G1 better than G2
| | - Duration of illness ( < 3 yrs, ≥ 3 yrs).; - Current wt (86 – 110% and > 111% of MPMW); - Probably hx of AN (adult wt < 85% of MPMW) | NR | | | | NA | G1: 41.4 (38.7) | G1: 7.5 (13.5) (P = NR) | SCL-90-R, mean (SD): | SCL-90-R, mean (SD):
| | Completers (N: 50) | Height, in, mean (SD): | | | | Funding: | G2: 44.1 (30.5) | G2: 16.7 (18.5) (P = NR) | G1: 1.1 (0.7) | G1: 0.6 (0.7)(P = NR)
| | G1: 25 | G1: 65.6 (3.0) | | | | Health and Welfare Canada project grant, NATO Grants for Collaborative Research, Research Associate Award, Research FellowshiP from the Ontario Mental Health Foundation | (P = NS) | Diff between groups (P = NR) | G2: 1.3 (0.6) | G2: 1.0 (0.6) (P = NR)
| | G2: 25 | G2: 66.1 (2.5) | | | | | | Diff between groups in change over time (P = NS) | (P = NS) | Diff over time (P = NR)
| | In a few cases a patient who should have been assigned to 1 tx was assigned to the other because therapists in the assigned condition were unavailable to accept a referral at the time. Also, any patient who dropped out was replaced by the next suitable patient, who was assigned to the same tx cell, in order to obtain 25 patients who completed each tx. | (P = NS) | | | | | | Reduction in vomiting frequency, %: | | Diff between groups (P = NR)
| | | Wt, lbs, mean (SD): | | | | | | G1: 81.9 | | Diff between groups in change over time (P = 0.03)
| | | G1: 126.4 (16.4) | | | | | | G2: 62.1 | | G1 better than G2
| | | G2: 126.6 (13.1) | | | | | | Diff between groups (P = NS) | RSE, mean (SD): | RSE, mean (SD):
| | | (P = NS) | | | | | | Improvement in vomiting frequency of at least 50%: | G1: 25.0 (5.7) | G1: 29.4 (6.2) (P = NR)
| | | Current wt, % of matched population mean (MPMW), mean (SD): | | | | | | G1: 92% | G2: 23.7 (5.3) | G2: 25.6 (5.2) (P = NR)
| | | G1: 95.3 (9.8) | | | | | | G2: 68.0% | (P = NS) | Diff over time (P = NR)
| | | G2: 94.9 (7.9) | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | (P = NS) | | | | | | Vomiting abstinence, past 28 days, N (%): | | Diff between groups in change over time (P = 0.03)
| | | Maximum wt, % MPMW, mean (SD): | | | | | | G1: 9 (36.0%) | | G1 better than G2
| | | G1: 108.6 (9.9) | | | | | | G2: 3 (12.0%) | Millon Borderline subscale, mean (SD): | Millon Borderline subscale, mean (SD):
| | | G2: 111.8 (12.7) | | | | | | Diff between groups (P = NR) | G1: 73.4 (17.9) | G1: 56.8 (17.4) (P = NR)
| | | (P = NS) | | | | | EAT Dieting, mean (SD): | EAT Dieting, mean (SD): | G2: 75.0 (13.3) | G2: 73.7 (20.6) (P = NR)
| | | Min wt. % MPMW, mean (SD): | | | | | G1: 20.6 (8.6) | G1: 6.8 (5.9) (P = NR) | (P = NS) | Diff between groups (P = NR)
| | | G1: 84.3 (10.0) | | | | | G2: 19.7 (7.7) | G2: 12.5 (9.5) (P = NR) | | Diff between groups in change over time (P = 0.005)
| | | G2: 82.9 (8.7) | | | | | (P = NS) | Diff between groups (P = NR) | | G1 better than G2
| | | (P = NS) | | | | | | Diff between groups in change over time (P = 0.008) | Millon Dysthymia subscale, mean (SD): | Millon Dysthymia subscale, mean (SD):
| | | Duration of illness, mo, mean (SD): | | | | | | G1 better than G2 | G1: 85.1 (17.4) | G1: 65.6 (18.3) (P = NR)
| | | G1: 71.8 (47.6) | | | | | EAT Bulimia and food preoccupation, mean (SD): | EAT Bulimia and food preoccupation, mean (SD): | G2: 89.2 (15.4) | G2: 88.1 (16.8) (P = NR)
| | | G2: 71.2 (40.2) | | | | | G1: 11.2 (4.3) | G1: 2.0 (3.7) (P = NR) | (P = NS) | Diff between groups (P = NR)
| | | (P = NS) | | | | | G2: 10.9 (4.0) | G2: 4.9 (4.5) (P = NR) | | Diff between groups in change over time (P = 0.0001)
| | | Binge episodes, past 28 days, mean (SD) (range): | | | | | (P = NS) | Diff between groups (P = NR) | | G1 better than G2
| | | 27.5 (25.1) (0–140) | | | | | | Diff between groups in change over time (P = 0.01)
| | | Vomiting episodes, past 28 days, mean (SD) (range): | | | | | | G1 better than G2
| | | 42.2 (32.6) (8–154) | | | | | EAT Oral control, mean (SD): | EAT Oral control, mean (SD):
| | | | | | | | G1: 2.9 (2.9) | G1: 1.6 (1.4) (P = NR)
| | | | | | | | G2: 2.8 (3.6) | G2: 1.3 (1.9) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EAT Total, mean (SD): | EAT Total, mean (SD):
| | | | | | | | G1: 34.7 (12.7) | G1: 10.4 (9.1) (P = NR)
| | | | | | | | G2: 33.2 (11.6) | G2: 18.7 (14.1) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.01)
| | | | | | | | | G1 better than G2
| | | | | | | | EDE Dietary restraint, mean (SD): | EDE Dietary resraint, mean (SD):
| | | | | | | | G1: 3.7 (1.3) | G1: 1.5 (1.7) (P = NR)
| | | | | | | | G2: 3.2 (1.5) | G2: 2.5 (1.6) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.009)
| | | | | | | | | G1 better than G2
| | | | | | | | EDE Attitudes toward shape, mean (SD): G1: 3.3 (1.4) | EDE Attitudes toward shape, mean (SD):
| | | | | | | | G2: 3.6 (1.0) | G1: 2.0 (1.3) (P = NR)
| | | | | | | | (P = NS) | G2: 2.9 (1.1) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.02)
| | | | | | | | | G1 better than G2
| | | | | | | | EDE Attitudes toward wt, mean (SD): | EDE Attitudes toward wt, mean (SD):
| | | | | | | | G1: 2.4 (1.4) | G1: 1.6 (1.2) (P = NR)
| | | | | | | | G2: 2.9 (1.1) | G2: 2.4 (1.1) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE Bulimia: | EDE Bulimia:
| | | | | | | | G1: NR | G1: NR
| | | | | | | | G2: NR | G2: NR
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE Eating concerns: | EDE Eating concerns:
| | | | | | | | G1: NR | G1: NR
| | | | | | | | G2: NR | G2: NR
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.02)
| | | | | | | | | G1 better than G2
| | | | | | | | EDI Drive for thinness: mean (SD) | EDI Drive for thinness, mean (SD):
| | | | | | | | G1: 14.3 (4.4) | G1: 5.9 (6.3) (P = NR)
| | | | | | | | G2: 14.1 (5.2) | G2: 9.4 (6.8) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDI Bulimia, mean (SD): | EDI Bulimia, mean (SD):
| | | | | | | | G1: 11.6 (4.9) | G1: 2.2 (3.9) (P = NR)
| | | | | | | | G2: 10.2 (6.2) | G2: 4.8 (4.5) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.002)
| | | | | | | | | G1 better than G2
| | | | | | | | EDI Body dissatisfaction, mean (SD): | EDI Body dissatisfaction, mean (SD):
| | | | | | | | G1: 15.5 (8.4) | G1: 11.7 (9.0) (P = NR)
| | | | | | | | G2: 16.7 (8.0) | G2: 13.7 (7.5) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Treatment Satisfaction:
| | | | | | | | | Tx X Outcome Interaction (P = 0.02). G1 with good outcome were more satisfied with tx than G1 with poor outcomes or G2 with either good or poor outcomes. Good outcome = vomiting ≤ 4 episodes/mo)
Author, yr: | Research objective: | Groups: | Total Sample (N = 78) | Inclusion: | Both forms of manualized tx were and conducted for 8 wks and included 7 individual, 50 to 60 minute long sessions (6 with therapist, 1 with dietitian). CBT manual based on Fairburn (1985); HBT manual based on Griffiths (1989). | T-tests and chi-square analyses done to examine baseline Diffs. MANOVA used to explore group Diffs. The variables of ‘episodes of bingeing’ and ‘episodes of purging’ underwent log transformations. Post tx for G1 refers to the last wk of waiting for tx (wk 9). | Score: | EAT-40, mean (SD): | EAT-40, mean (SD):
Griffiths et al., 1994 | Compare immediate post-tx effects of CBT, HBT and a wait list control group in treating BN. | G1: Wait list control (N = 28) | Age, yrs, mean (SD): | Female; age 17 to 50 yrs; BMI 18 to 26; no more than 2 prior inpatient admissions for an ED; willing to participate in research and FU; willing to not seek additional tx during research study. | HBT: used hypnosis to reinforce what was taught within the CBT component. CBT: cognitive explanation of BN and used cognitive techniques. | | Poor | G1: 53 (16.06) | G1: 45.73 (17.99) (P = NR)
Setting: | | G2: CBT (N = 23) | Total sample: | Exclusion: | Waitlist: did not complete the full assessment at baseline. They were asked to keep a baseline eating diary for 1 wk after their intake interview and another 1-wk diary before attending their appointment 8 wks later. They were not contacted during the tx. | | Intent to treat: | G2: 46.63 (16.04) | G2: 18.79 (11.65) (P = NR)
Teaching hospital, Sydney, Australia Outpatient | | G3: Hypnobehavioral therapy (HBT) (N = 27) | 25.91 (5.73) | Concurrent psychological or pharmacological tx; Coexisting major psychiatric disorder other than depressive or anxiety state or personality disorder; Physical dependence on drugs or alcohol; Suicide risk or poor physical health indicating need for hospitalization. | | | Yes; however only completer results are presented in tables. | G3: 47.62 (19.91) | G3: 25.91 (20.56) (P = NR)
Enrollment period: | | Enrollment: | G1: 27.1 (1.24) | | | | Blinding: | (P = NR) | Diff between groups (P = NR)
NR | | - Participants were recruited via media as well as referrals from the Eating Disorders Clinic within test site.; - 130 participants presented with symptoms of BN; - 85 completed the assessments and met criteria; - 78 participants entered tx and were randomized to one of the 3 tx groups; - 63 participants completed tx. | G2+G3: 24.4 (1.2) | | | | NA | | Diff between groups in change over time G2+G3 better than G1 (P < 0.001)
| | | (P < 0.05) | | | | Adverse events: | | G2 vs. G3 (P = NS)
| | | Sex: | | | | NR | EAT-26 - Dieting, mean (SD): | EAT-26 - Dieting, mean (SD):
| | | Female: 100% | | | | Funding: | G1: 21.41 (7.86) | G1: 18.96 (9.36) (P = NR)
| | | Race/ethnicity: | | | | NR | G2: 19.53 (9.62) | G2: 7.53 (6.48) (P = NR)
| | | NR | | | | | G3: 20.67 (9.19) | G3: 11.19 (10.54) (P = NR)
| | | BMI, kg/m ^ 2 ^ , mean (SD): | | | | | (P = NR) | Diff between groups (P = NR)
| | | 21.89 (2.01) | | | | | | Diff between groups in change over time G2+G3 better than G1 (P < 0.001)
| | | Height, cms, mean (SD): | | | | | | G2 vs. G3 (P = NS)
| | | G1: NR | | | | | EAT-26 – Bulimia and Food Preoccupation, mean (SD): | EAT-26 – Bulimia and Food Preoccupation, mean (SD):
| | | G2: 165.60 (7.04) | | | | | G1: 12.73 (3.72) | G1: 10.55 (5.18) (P = NR)
| | | G3: 162.45 (5.35) | | | | | G2: 11.53 (3.85) | G2: 1.95 (2.55) (P = NR)
| | | (P < 0.05) | | | | | G3: 10.86 (4.77) | G3: 3.33 (3.93) (P = NR)
| | | Duration of bulimic symptoms, yrs, mean (SD): | | | | | (P = NR) | Diff between groups (P = NR)
| | | Total: 6.19 (5.08) | | | | | | Diff between groups in change over time G2+G3 better than G1 (P < 0.001)
| | | G1: NR | | | | | | G2 vs. G3 (P = NS)
| | | G2: 5.40 (2.31) | | | | | EAT-26 - Oral Control, mean (SD): | EAT-26 - Oral Control, mean (SD):
| | | G3: 3.31 (2.99) | | | | | G1: 3.41 (1.27) | G1: 10.55 (5.18) (P = NR)
| | | (P < 0.05) | | | | | G2: 2.16 (0.74) | G2: 1.95 (2.55) (P = NR)
| | | Duration of objective bulimic episodes, yrs, mean (SD): | | | | | G3: 3.67 (1.97) | G3: 3.33 (3.93) (P = NR)
| | | Total: 4.54 (5.15) | | | | | G2 lower than G3 (P < 0.05) | Diff between groups (P = NR)
| | | G1: NR | | | | | | Diff between groups in change over time G2+G3 better than G1 (P < 0.001)
| | | G2: 3.42 (3.14) | | | | | | G2 vs. G3 (P = NS)
| | | G3: 1.96 (3.04) | | | | | EDI-DT, mean (SD): | EDI-DT, mean (SD):
| | | (P < 0.05) | | | | | G1: 15.46 (4.22) | G1: 13.55 (5.33) (P = NR)
| | | Frequency (days/mo) of objective bulimic episodes, mean (SD): | | | | | G2: 14.32 (5.39) | G2: 7.58 (6.17) (P = NR)
| | | 14.18 (7.78) | | | | | G3: 14.95 (5.38) | G3: 8.62 (7.07) (P = NR)
| | | Frequency (days/mo) of self-induced vomiting,mean (SD): | | | | | (P = NR) | Diff between groups (P = NR)
| | | 15.76 (10.40) | | | | | | Diff between groups in change over time (P = NS)
| | | Frequency (days/mo) of laxative abuse, mean (SD): | | | | | EDI-B, mean (SD): | EDI-B, mean (SD):
| | | 4.69 (8.67) | | | | | G1: 12.18 (4.24) | G1: 11.14 (5.14) (P = NR)
| | | Hx of AN: | | | | | G2: 11.58 (4.07) | G2: 3.32 (5.24) (P = NR)
| | | 25.6% | | | | | G3: 10.76 (4.97) | G3: 3.76 (4.63) (P = NR)
| | | Serious psychological condition: | | | | | (P = NR) | Diff between groups (P = NR)
| | | 20.5% | | | | | | Diff between groups in change over time G2+G3 better than G1 (P < 0.001)
| | | Suicide attempts: | | | | | | G2 vs. G3 (P = NS)
| | | 24.4% | | | | | EDI-BD, mean D (SD): | EDI-BD, mean (SD):
| | | Abused alcohol/drugs or both substances: | | | | | G1: 18.32 (8.69) | G1: 17.41 (8.17) (P = NR)
| | | 21.8% | | | | | G2: 19.47 (7.94) | G2: 14.21 (8.65) (P = NR)
| | | Previous tx for AN, BN or obesity: | | | | | G3: 18.09 (7.27) | G3: 12.62 (7.95) (P = NR)
| | | 28.2% | | | | | (P = NR) | Diff between groups (P = NR)
| | | Marital status: | | | | | | Diff between groups in change over time (P = NS)
| | | Single: 78.2% | | | | | Number of days bingeing, mean (SD): | Number of days bingeing, mean (SD):
| | | Married: 12.8% | | | | | G1: 4.77 (1.83) | G1: 4.14 (2.21) (P = NR)
| | | Separated: 2.6% | | | | | G2: 3.18 (1.49) | G2: 1.25 (1.45) (P = NR)
| | | Divorced: 5.1% | | | | | G3: 3.95 (1.67) | G3: 1.62 (2.09) (P = NR)
| | | Widowed: 1.3% | | | | | (P = NR) | Diff between groups (P = NR)
| | | Employment status: | | | | | | Diff between groups in change over time G2+G3 better than G1 (P < 0.01)
| | | Employed: 64.1% | | | | | | G2 vs. G3 (P = NS)
| | | Students: 14.1% | | | | | Number of days purging, mean (SD): | Number of days purging, mean (SD):
| | | Unemployed: 11.5% | | | | | G1: 5.27 (2.00) | G1: 4.95 (2.38) (P = NR)
| | | Food-related employment: 6.5% | | | | | G2: 3.38 (2.29) | G2: 0.95 (1.23) (P = NR)
| | | Home duties: 3.8% | | | | | G3: 3.86 (2.46) | G3: 1.67 (1.98) (P = NR)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time G2+G3 better than G1 (P < 0.001)
| | | | | | | | | G2 vs. G3 (P = NS)
| | | | | | | | Episodes bingeing, mean (SD): | Episodes bingeing, mean (SD):
| | | | | | | | G1: 9.82 (9.49) | G1: 8.77 (11.05) (P = NR)
| | | | | | | | G2: 4.73 (2.79) | G2: 1.50 (2.01) (P = NR)
| | | | | | | | G3: 6.38 (6.12) | G3: 2.00 (2.62) (P = NR)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time G2+G3 better than G1 (P < 0.001)
| | | | | | | | | G2 vs. G3 (P = NS)
| | | | | | | | Episodes purging, mean (SD): | Episodes purging, mean (SD):
| | | | | | | | G1: 11.27 (9.87) | G1: 11.27 (12.09) (P = NR)
| | | | | | | | G2: 6.48 (7.43) | G2: 1.25 (1.77) (P = NR)
| | | | | | | | G3: 8.55 (9.94) | G3: 2.19 (3.52) (P = NR)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time G2+G3 better than G1 (P < 0.001)
| | | | | | | | | G2 vs. G3 (P = NS)
| | | | | | | | | Abstinence from bingeing:
| | | | | | | | | G1: 4.5%
| | | | | | | | | G2: 50%
| | | | | | | | | G3: 43%
| | | | | | | | | (P = NR)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Length: 14 wks (2 sessions for the first wk and then wkly) | Baseline characteristics: | Score: | Binge episodes/wk, mean (SD): | Change in binge episodes/wk, mean (SD): | HDRS, mean (SD): | Change HDRS, mean (SD):
Hsu et al., 2001 | To compare the efficacy of CT, NT, the combination (CNT), against a control support group in the tx of BN. | G1: Nutritional (NT) (N = 23) | Total sample: 24.5 (6.4) | Female, DSM III-R criteria for BN, within 85 – 125% of IBW, between 17 – 45 yrs old, BE and vomiting at least 3 times per wk in previous 6 mo, absence of: alcohol or substance abuse in previous 12 mo, psychotic features, suicide attempt within last 6 mo, psychotropic meds. | CNT: 16 2-hr sessions (1 hr of each) | ANOVA and chi-square | Fair | Total sample: 10.9 (9.5) | G1: -8.39 (10.43) (P = NR) | Total sample: 17.64 (8.01) | G1: -5.96 (11.11) (P = NR)
Setting: | | G2: Cognitive Therapy (CT) (N = 26) | G1: 24.2 (5.6) | Exclusion: | NT: 16 1-hr sessions aimed at helping patient to understand good nutrition, nutritional needs, relationship between nutrition and BE, meal planning, buying meals. | Outcomes: chi-squared contingency tests, Kruskal-Wallis non-parametric ANOVA, Mann-Whitney tests, ANCOVA followed by specific paired comparisons using least sig Diff. | Intent to treat: | G1: 12.3 (10.8) | G2: -4.92 (4.97) (P = NR) | G1: 18.04 (7.54) | G2: -4.46 (7.98) (P = NR)
Outpatient Boston, MA, USA | | G3: Combined cognitive-nutritional (CNT) (N = 27) | G2: 23.3 (5.0) | None | CT: 16 1-hr sessions aimed at helping identify antecedents of bulimic episodes, thoughts/feelings/function/beliefs of episodes. Help develop alternative coping bx, cognitive restructuring, problem solving. 6 sessions of EXRP | Completion rates and abstinence relative to type of tx: | Yes | G2: 7.2 (4.3) | G3: -9.41 (7.59) (P = NR) | G2: 14.92 (8.04) | G3: -8.33 (7.35) (P = NR)
Enrollment period: | | G4: Support (SG) (N = 24) | G3: 24.1 (5.3) | | SG: 14, 90-minute sessions led by 2 recovered patients and a mother of a recovered patient. Open support groups of 6–8 patients. | Multiple linear and logistic regression with covariates | Blinding: | G3: 12.1 (7.0) | G4: -5.79 (11.44) (P = NR) | G3: 18.89 (8.28) | G4: -4.33 (8.08) (P = NR)
NR | | Enrollment: | G4: 26.5 (9.1) | | | | NA | G4: 12.2 (13.4) | Diff over time (P < 0.001) | G4: 18.79 (7.86) | Diff over time (P < 0.001)
| | 100 randomized (stratified according to presence of concurrent major depression) | (P = NS) | | | | Adverse events: | (P = NS) | Diff between groups in change over time (P = NS) | (P = NS) | Diff between groups (P = NR)
| | Completion, N (%): | Sex: | | | | NR | Vomiting episodes/wk, mean (SD): | Change in vomit episodes/wk, mean (SD): | | Diff between groups in change over time (P = NS)
| | Total sample: 73 (73%) | Female: 100% | | | | Funding: | Total sample: 12.2 (10.3) | G1: -9.43 (11.42) (P = NR)
| | G1: 14 (61%) | Race/ethnicity: | | | | NICHD | G1: 13.3 (11.2) | G2: -5.73 (5.02) (P = NR)
| | G2: 22 (85%) | NR | | | | General Clinical Research Center at New England Medical Center funded by the National Center for Research Resources of the NIH | G2: 7.7 (5.0) | G3: -10.56 (8.42) (P = NR)
| | G3: 24 (89%) | Duration of BN, yrs, mean (SD): | | | | | G3 13.4 (9.2) | G4: -4.58 (13.28) (P = NR)
| | G4: 13 (54%). | Total sample: 5.7 (4.5) | | | | | G4: 14.5 (13.6) | Diff over time (P < 0.001)
| | G3 vs. G4 (P = 0.006) | G1: 5.0 (4.4) | | | | | (P = NS) | Diff between groups in change over time (P = NS)
| | G2 vs. G4 (P = 0.02) | G2: 5.5 (3.2) | | | | | Meals eaten/wk, mean (SD): | Change in meals eaten/wk, mean (SD):
| | G3 vs. G1 (P = 0.02) | G3: 5.9 (3.7) | | | | | Total sample: 10.8 (6.7) | G1: 4.87 (6.97) (P = NR)
| | Wks in tx, mean (SD): | G4: 6.4 (6.3) | | | | | G1: 11.4 (6.8) | G2: 5.42 (6.50) (P = NR)
| | G1: 10.91 (4.42) | (P = NS) | | | | | G2: 10.0 (7.1) | G3: 7.07 (5.86) (P = NR)
| | G2: 12.92 (2.91) | Hx of AN, N (%): | | | | | G3: 10.9 (5.8) | G4: 3.79 (7.83) (P = NR)
| | G3: 12.78 (3.56) | Total sample: 41 (41%) | | | | | G4: 11.0 (7.3) | Diff over time (P < 0.001)
| | G4: 9.21 (5.61) | G1: 9 (39%) | | | | | (P = NS) | Diff between groups in change over time (P = NS)
| | G3 vs. G4 (P = 0.007) | G2: 10 (38%) | | | | | | Abstinence (no binge/purge in wk prior to post tx, N (%):
| | G2 vs. G4 (P = 0.01) | G3: 11 (4%1) | | | | | | G1: 4/23 (17%)
| | G3 vs. G1 (P = 0.039) | G4: 11 (46%) | | | | | | G2: 9/26 (35%)
| | | (P = NS) | | | | | | G3: 14/27 (52%)
| | | Previous tx for BN, N (%): | | | | | | G4: 5/24 (24%)
| | | Total sample: 46 (46%) | | | | | | G1 vs. G4 (P = NS)
| | | G1: 11 (48%) | | | | | | G2 vs. G4 (P = NS)
| | | G2: 11 (42%) | | | | | | G3 vs. G4 (P = 0.022)
| | | G3: 11 (41%) | | | | | | G3 vs. G1 (P = 0.011)
| | | G4: 13 (54%) | | | | | | EDI-Drive for Thinness:
| | | (P = NS) | | | | | | G1: NR
| | | % ABW, mean (SD): | | | | | | G2: NR
| | | Total sample: 112.2 (9.5) | | | | | | G3: NR
| | | G1: 114.5 (9.4) | | | | | | G4: NR
| | | G2: 112.5 (9.6) | | | | | | Diff over time (P = NR)
| | | G3: 110.2 (8.7) | | | | | | Diff between groups (P = NR)
| | | G4: 111.9 (10.4) | | | | | | Diff between groups in change over time (P = NR)
| | | (P = NS) | | | | | | G1 vs. G4 (P = NS)
| | | | | | | | | G2 vs. G4 (P = 0.011)
| | | | | | | | | G2 vs. G1 (P = NS)
| | | | | | | | | G3 vs. G4 (P < 0.001)
| | | | | | | | | G3 vs. G1 (P = 0.006)
| | | | | | | | | EDI-Bulimia:
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | G1 vs. G4 (P = NS)
| | | | | | | | | G2 vs. G4 (P = NS)
| | | | | | | | | G2 vs. G1 (P = 0.029)
| | | | | | | | | G3 vs. G4 (P < 0.0045)
| | | | | | | | | G3 vs. G1 (P = 0.006)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Groups (co-led by 2 therapists) of 5–8 participants in 15 two-hour sessions over a 3-mo period. The first 7 sessions were the intensive phase within the first 3 wks. The remaining 8 sessions were conducted on a wkly basis. Manuals were followed. | Repeated measures MANOVA with 1 within factor (time) and 2 between factors (tx and center). | Score: | Binge frequency, per wk, mean (SD): | Binge frequency/wk, mean (SD): | BDI, mean (SD): | BDI, mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD):
Laessle et al., 1991 | To evaluate the efficacy of a nutritional-management program which was aimed at modifying restrained eating vs. stress management in BN | G1: Nutritional management (N = 27) | 23.8 (3.8) | DSM III-R criteria for BN, female age 18 to 35 yrs, BMI between 18 to 24, not more than 2 previous inpatient tx for psychiatric conditions, no co-existing major psychiatric disorder other than affective or anxiety, no indications for inpatient tx because of either a serious suicide risk or poor physical health. | G1: Discussed metabolic processes, energy requirements, body wt, biological and psychological effects of dieting; analysis of nutritional diaries and modification of inadequate patterns; advice on eating patterns, stimulus control, meal preparation was offered. | Tested linear and quadratic trends over time. | Fair | G1: 11.8 (10.6) | 3 wks: | G1: 19.5 (12.6) | 3 wks: | G1: 21.2 (1.8) | 3 wks:
Setting: | | G2: Stress management (N = 28) | Sex: | Exclusion: | G2: functional analysis of stressful situations relevant to BE; short term strategies to alter coping behavior in stressful situations, progressive muscle relaxation, problem solving, communication skills. No specific intervention to alter restrained eating, no individualized meal plan or homework. | Tested separate models for the pre-tx to post-tx effects vs. the post-tx to 12 mo FU. | Intent to treat: | G2: 14.0 (12.0) | G1: 4.0 (6.5) (P = NR) | G2: 23.0 (9.5) | G1: 13.8 (11.8) (P = NR) | G2: 20.6 (1.9) | G1: 21.8 (1.7) (P = NR)
Munich, Germany; Sydney, Australia; outpatient | | Enrollment: | Female: 100% | None | | Binge and vomiting behavior data were log-transformed. | Yes | (P = NS) | G2: 9.2 (13.0) (P = NR) | (P = NS) | G2: 12.2 (9.9) (P = NR) | (P = NS) | G2: 20.7 (2.5) (P = NR)
Enrollment period: | | Screened: N = 85 | Race/ethnicity: | | | Fisher's exact tests used to evaluate diffs in abstinence rates. | Blinding: | | Post-tx: | | Post-tx: | | Post-tx:
NR | | Randomized: N = 55 | NR | | | | NA | | G1: 3.5 (6.1) (P = NR) | | G1: 9.3 (9.2) (P = NR) | | G1: 22.0 (1.9) (P = NR)
| | Drop out, N: | Duration of Bulimic symptoms, yrs, mean (SD): | | | | Adverse events: | | G2: 4.2 (7.2) (P = NR) | | G2: 11.8 (12.5) (P = NR) | | G2: 20.7 (2.0) (P = NR)
| | G1: 5 | 7.5 (3.8) | | | | 1 patient hospitalized during FU | | Diff over time (P < 0.0001) | | Diff over time (P < 0.0001) | | Diff over time (P = NS)
| | G2: 2 | Bulimic episodes per wk, mean (SD): | | | | Funding: | | Diff between groups (P = NR) | | Diff between groups (P = NR) | | Diff between groups (P = NS)
| | (P = NS) | 13.3 (10.8) | | | | NR | | Diff between groups in change over time (linear trend, P = NS) (quadratic trend, P < 0.05). | | Diff between group in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | Reported vomiting, N (%): | | | | | | After 3 wks, G1 better than G2 | | 6 mo: | | 6 mo:
| | | 50 (90.9) | | | | | | 6 mo: | | G1: 8.3 (7.2) (P = NR) | | G1:NR
| | | Reported laxative use, N (%): | | | | | | G1: 1.7 (3.4) (P = NR) | | G2: 7.8 (9.5) (P = NR) | | G2: NR
| | | 19 (34.5) | | | | | | G2: 3.0 (4.5) (P = NR) | | 12 mo: | | 12 mo:
| | | Vomiting frequency, episodes per wk, mean (SD): | | | | | | 12 mo: | | G1: 5.1 (8.0) (P = NR) | | G1: NR
| | | 14.8 (12.4) | | | | | | G1: 1.0 (1.9) (P = NR) | | G2: 8.3 (9.7) (P = NR) | | G2: NR
| | | Current BMI, mean (SD): | | | | | | G2: 2.6 (4.8) (P = NR) | | Diff between groups (P = NR) | | Diff over time (P = NS)
| | | 21.0 (1.8) | | | | | | Diff over time (P < 0.01) | | Diff between group in change over time (P = NS) | | Diff between groups (P = NS)
| | | Max adult BMI, mean (SD): | | | | | | Diff between groups (P = NS) | | | | Diff between groups in change over time (P = NR)
| | | 24.4 (4.2) | | | | | | Diff between groups in change over time (P = NS) | STAI-State, mean (SD): | STAI-State, mean (SD):
| | | Min adult BMI, mean (SD): | | | | | | Binge Abstinence rates, %: | G1: 49.6 (12.9) | 3 wks:
| | | G1: 18.2 (1.8) | | | | | | 3 wks: | G2: 52.0 (13.2) | G1: 46.2 (14.4) (P = NR)
| | | G2: 16.8 (2.1) | | | | | | G1: 29.6 | (P = NS) | G2: 45.8 (13.5) (P = NR)
| | | (P < 0.01) | | | | | | G2: 14.3 | | Post-tx:
| | | Previously met criteria for AN, N (%): | | | | | | (P = NS) | | G1: 41.8 (13.8) (P = NR)
| | | 22 (40) | | | | | | Post-tx: | | G2: 43.4 (13.2) (P = NR)
| | | Current substance abuse problems, N (%): | | | | | | G1: 40.7 | | Diff over time (P < 0.0001)
| | | 7 (12.7) | | | | | | G2: 25.0 | | Diff between groups (P = NS)
| | | Previous psychiatric/ psychological tx, N: | | | | | | (P = NS) | | Diff between groups in change over time (P = NS)
| | | 29 | | | | | | 6 mo: | | 6 mo:
| | | AN = 7 | | | | | | G1: 60 | | G1: 13.5 (12.2) (P = NR)
| | | BN = 19 | | | | | | G2: 25 | | G2: 42.0 (14.5) (P = NR)
| | | Depression = 3 | | | | | | (P = 0.01) | | 12 mo:
| | | Previous hospital admission, N: | | | | | | G1 better than G2 | | G1: 38.9 (12.8) (P = NR)
| | | 9 | | | | | | 12 mo: | | G2: 44.2 (16.2) (P = NR)
| | | AN = 6 | | | | | | G1: 56 | | Diff between groups (P = NS)
| | | BN = 3 | | | | | | G2: 25 | | Diff between groups in change over time (P = NS)
| | | Marital status, married or regular partner in heterosexual relationship, N (%): | | | | | | (P = 0.04) | STAI-Trait, mean (SD): | STAI-Trait, mean (SD):
| | | 27 (49.1) | | | | | | G1 better than G2 | G1: 55.2 (10.5) | 3 wks:
| | | Employment status, N (%): | | | | | Vomiting frequency, episodes per wk, mean (SD): | Vomiting frequency/ wk, mean (SD): | G2: 59.8 (7.4) | G1: 50.7 (13.2) (P = NR)
| | | HS student: 6 (11.0) | | | | | G1: 11.3 (8.5) | 3 wks: | (P = NS) | G2: 52.2 (9.8) (P = NR)
| | | Tertiary student: 19 (34.5) | | | | | G2: 16.9 (13.9) | G1: 4.5 (7.3) (P = NR) | | Post-tx:
| | | Employed: 24 (42.6) | | | | | (P = NS) | G2: 10.0 (13.6) (P = NR) | | G1: 47.2 (12.3) (P = NR)
| | | Unemployed: 6 (11.0) | | | | | | Post-tx: | | G2: 45.4 (11.6) (P = NR)
| | | | | | | | | G1: 3.7 (7.0) (P = NR) | | Diff over time (P < 0.0001)
| | | | | | | | | G2: 5.5 (8.8) (P = NR) | | Diff between groups (P = NR)
| | | | | | | | | Diff over time (P < 0.0001) | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | Diff between groups (P = NS) | | G2 better then G1
| | | | | | | | | Diff between groups in change over time (P = NS) | | 6 mo:
| | | | | | | | | 6 mo: | | G1: 46.4 (11.9) (P = NR)
| | | | | | | | | G1: 2.2 (4.2) (P = NR) | | G2: 44.5 (11.5) (P = NR)
| | | | | | | | | G2: 3.3 (4.5) (P = NR) | | 12 mo:
| | | | | | | | | 12 mo: | | G1: 44.6 (11.6) (P = NR)
| | | | | | | | | G1: 2.5 (5.2) (P = NR) | | G2: 45.8 (12.8) (P = NR)
| | | | | | | | | G2: 3.1 (5.1) (P = NR) | | Diff between groups (P = NS)
| | | | | | | | | Diff over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Vomiting Abstinence rates (%):
| | | | | | | | | 3 wks:
| | | | | | | | | G1: 40.7
| | | | | | | | | G2: 21.4
| | | | | | | | | (P = NS)
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 48.1
| | | | | | | | | G2: 32.1
| | | | | | | | | (P = NS)
| | | | | | | | | 6 mo:
| | | | | | | | | G1: 50
| | | | | | | | | G2: 29
| | | | | | | | | (P = NS)
| | | | | | | | | 12 mo:
| | | | | | | | | G1: 56
| | | | | | | | | G2: 33
| | | | | | | | | (P = NS)
| | | | | | | | EAT, mean (SD): | EAT, mean (SD):
| | | | | | | | G1: 51.0 (19.1) | 3 wks:
| | | | | | | | G2: 51.4 (17.2) | G1: 29.9 (20.9) (P = NR)
| | | | | | | | (P = NS) | G2: 39.7 (15.4) (P = NR)
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 27.3 (19.3) (P = NR)
| | | | | | | | | G2: 28.9 (21.6) (P = NR)
| | | | | | | | | Diff over time (linear trend (P < 0.0001) (quadratic trend, P < 0.05)
| | | | | | | | | Most improvements during the first three wks Diff between groups(P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 6 mo:
| | | | | | | | | G1: 24.9 (14.4) (P = NR)
| | | | | | | | | G2: 21.1 (14.9) (P = NR)
| | | | | | | | | 12 mo:
| | | | | | | | | G1: 20.6 (18.0) (P = NR)
| | | | | | | | | G2: 19.2 (16.5) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Calories per day, mean (SD): | Calories per day, mean (SD):
| | | | | | | | G1: 1228 (493) | 3 wk:
| | | | | | | | G2: 1071 (588) | G1: 1821 (664) (P = NR)
| | | | | | | | (P = NS) | G2: 1299 (545) (P = NR)
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 1697 (547) (P = NR)
| | | | | | | | | G2: 1584 (530) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups in change over time (quadratic trend, P < 0.05)
| | | | | | | | | G1 better than G2 after 3 wks
| | | | | | | | | 6 mo:
| | | | | | | | | G1: 1621 (509) (P = NR)
| | | | | | | | | G2: 1623 (556) (P = NR)
| | | | | | | | | 12 mo:
| | | | | | | | | G1: 1703 (589) (P = NR)
| | | | | | | | | G2: 1639 (649) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDI Drive for thinness, mean (SD): | EDI, Drive for thinness mean (SD):
| | | | | | | | G1: 13.8 (4.2) | 3 wks:
| | | | | | | | G2: 12.9 (5.3) | G1: 8.6 (5.2) (P = NR)
| | | | | | | | (P = NS) | G2: 9.1 (3.9) (P = NR)
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 7.4 (5.6) (P = NR)
| | | | | | | | | G2: 6.4 (4.7) (P = NR)
| | | | | | | | | Diff over time (linear trend, P < 0.0001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 6 mo:
| | | | | | | | | G1: 7.1 (5.7) (P = NR)
| | | | | | | | | G2: 5.8 (4.9) (P = NR)
| | | | | | | | | 12 mo:
| | | | | | | | | G1: 5.3 (4.6) (P = NR)
| | | | | | | | | G2: 6.2 (6.3) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDI Bulimia, mean (SD): | EDI Bulimia, mean (SD):
| | | | | | | | G1: 12.1 (4.6) | 3 wks:
| | | | | | | | G2: 12.2 (4.5) | G1: 5.8 (4.7) (P = NR)
| | | | | | | | (P = NS) | G2: 7.6 (4.9) (P = NR)
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 3.6 (4.9) (P = NR)
| | | | | | | | | G2: 4.7 (5.3) (P = NR)
| | | | | | | | | Diff over time (linear trend, P < 0.0001) (quadratic trend, P < 0.05)
| | | | | | | | | Most improvements during the first three wks
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 6 mo:
| | | | | | | | | G1: 3.2 (4.1) (P = NR)
| | | | | | | | | G2: 5.1 (5.3) (P = NR)
| | | | | | | | | 12 mo:
| | | | | | | | | G1: 3.0 (3.7) (P = NR)
| | | | | | | | | G2: 5.2 (5.6) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDI Body dissatisfaction, mean (SD): G1: 16.1 (6.9) | EDI Body dissatisfaction, mean (SD):
| | | | | | | | G2: 15.1 (6.9) | 3 wks:
| | | | | | | | (P = NS) | G1: 13.4 (7.0) (P = NR)
| | | | | | | | | G2: 11.3 (5.6) (P = NR)
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 13.0 (7.3) (P = NR)
| | | | | | | | | G2: 10.5 (6.6)
| | | | | | | | | Diff over time (linear trend, P < 0.0001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 6 mo:
| | | | | | | | | G1: 12.5 (8.6) (P = NR)
| | | | | | | | | G2: 10.6 (6.8) (P = NR)
| | | | | | | | | 12 mo:
| | | | | | | | | G1: 12.3 (7.6) (P = NR)
| | | | | | | | | G2: 11.4 (6.6) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | 20 sessions of wkly 50-minute individual psychotherapy specifically aimed at teaching emotional regulation skills to reduce rates of bingeing and purging. Tx manual was adapted for BN from Linehan's skills training manual for txing BPD. | Binge eating and purging: square root transformation and ANCOVA (baseline measures as covariates). Bonferroni corrections. | Score: | | After Bonferroni correction for multiple comparisons, diffs sig at P = 0.0045 | | After Bonferroni correction for multiple comparisons, diffs sig at P = 0.0045 | | NR
Safer, Telch, and Agras, 2001 | To examine the effects of DBT adapted for the tx of binge/purge behaviors. | G1: DBT (N = 16) | 34 (11) (range: 18–54) | At least 1 binge/purge per wk over the previous 3 mos (25 [80.6%] met full DSM criteria; 6 met modified criteria) | | | Good | EDE - Binge Episodes, past 4 wks, median: | EDE - Binge Episodes, past 4 wks, median: | Negative Mood Regulation Scale, mean (SD): | Mean Negative Mood Regulation Scale, mean (SD):
Setting: | | G2: Wait list control (N = 15) | Sex: | Exclusion: | | | Intent to treat: | G1: 27.0 | G1: 1.5 (P = NR) | G1: 81.3 (15.1) | G1: 96.1 (24.0) (P = NR)
Stanford, CA, USA | | Enrollment: | Female: G1: 100% | BMI < 17.5; psychosis or severe depression with suicidal ideation; active drug/alcohol abuse; concurrent participation in psychotherapy or use of antidepressants/ mood stabilizers. | | | Yes (for all participants with missing post tx data, but participants who were withdrawn for contraindications are not included in ITT). | G2: 22.0 | G2: 20.0 (P = NR) | G2: 98.1 (16.8) | G2: 97.7 (15.0) (P = NR)
Enrollment period: | | - N = 31; - G1: N = 16; - G2: N = 15; - Completed: N = 29; - G1: = 14; - G2: = 14 | Race/ethnicity: | | | | Blinding: | (P = NS) | Diff over time (P = NR) | (P = 0.02) | Diff over time (P = NR)
NR | | | White: 87.1% | | | | N/A | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | BMI, kg/m^2^, mean (SD): | | | | Adverse events: | | Diff between groups in change over time (P < 0.001) | | Diff between groups in change over time (P < 0.03)
| | | 23.7 (5.6) kg/m2 | | | | NR | EDE - Purge Episodes, past 4 wks, median: | EDE - Purge Episodes, past 4 wks, median: | BDI, mean (SD): | BDI, mean (SD):
| | | Employed: | | | | Funding: | G1: 40.0 | G1: 1.0 (P = NR) (P = NR) | G1: 22.9 (8.9) | G1: 13.4 (11.6) (P = NR)
| | | 51.6% | | | | NIH | G2: 28.0 | G2: 28.0 (P = NR) (P = NR) | G2: 19.2 (11.9) | G2: 17.4 (11.8) (P = NR)
| | | Full-time student: | | | | | (P = NS) | Diff over time (P = NR) | (P = NS) | Diff over time (P = NR)
| | | 22.6% | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | At least some college: | | | | | | Diff between groups in change over time (P = 0.002) | | Diff between groups in change over time (P < 0.04)
| | | 77.4% | | | | | Emotional Eating Scale subscale: | Mean Emotional Eating Scale subscale: | Positive and Negative Affect schedule subscale: | Positive and Negative Affect schedule subscale:
| | | Age at start of bulimic behavior, yrs, mean (SD): | | | | | Anger/frustration, mean (SD): | Anger/frustration, mean (SD): | Positive Affect, mean (SD): | Positive Affect, mean (SD):
| | | 22.3 (7.0) | | | | | G1: 2.7 (0.8) | G1: 1.8 (0.8) (P = NR) | G1: 24.8 (8.3) | G1: 27.6 (8.2) (P = NR)
| | | Duration of bulimic behaviors, yrs, mean (SD): | | | | | G2: 2.7 (0.6) | G2: 2.6 (0.9) (P = NR) | G2: 26.1 (6.5) | G2: 28.3 (7.9) (P = NR)
| | | 12.2 (8.6) | | | | | (P = NS) | Diff over time (P = NR) | (P = NS) | Diff over time (P = NR)
| | | Does not include 2 patients withdrawn from tx; No diff between groups on any baseline measures except the Negative Mood Regulation Scale score | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | (P = 0.02) | | | | | | Diff between groups in change over time (P = 0.006) | | Diff between groups in change over time (P = NS)
| | | | | | | | Emotional Eating Scale subscale: | Emotional Eating Scale subscale: | Negative Affect, mean (SD): | Negative Affect, mean (SD):
| | | | | | | | Anxiety, mean (SD): | Anxiety, mean (SD) | G1: 31.5 (9.9) | G1: 23.4 (8.4) (P = NR)
| | | | | | | | G1: 2.1 (0.8) | G1: 1.3 (0.9) (P = NR) | G2: 28.6 (6.9) | G2: 30.0 (9.7) (P = NR)
| | | | | | | | G2: 2.1 (0.9) | G2: 2.0 (0.8) (P = NR) | (P = NS) | Diff over time (P = NR)
| | | | | | | | (P = NS) | Diff over time (P = NR) | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups (P = NR) | | Diff between groups in change over time (P < 0.02)
| | | | | | | | | Diff between groups in change over time (P = 0.006)
| | | | | | | | Emotional Eating Scale subscale: | Emotional Eating Scale subscale:
| | | | | | | | Depression, mean (SD): | Depression, mean (SD):
| | | | | | | | G1: 2.9 (0.7) | G1: 2.1 (1.0) (P = NR)
| | | | | | | | G2: 2.7 (0.9) | G2: 2.6 (0.7) (P = NR)
| | | | | | | | (P = NS) | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.008)
| | | | | | | | | Abstinence rates:
| | | | | | | | | G1: N = 4 (28.6%)
| | | | | | | | | G2: N = 0 (0%)
| | | | | | | | | Diff between groups (P < 0.05)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | 16 wk outpatient tx for all groups | Group diffs were assessed by ANOVA for repeated measures and by paired-sample t-tests and nonparametric tests. P values < 0.05 were considered sig. | Score: | EDI Drive for Thinness, mean (SD): | EDI Drive for Thinness, mean (SD): | | | BMI, kg/m^2^, mean (SD): | Post-tx:
Sundgot-Borgen, et al., 2002 | To examine the effect of CBT vs physical exercise and vs nutritional counseling as tx for BN | G1: Exercise (N = 15) | G1: 23 (2.3) | Patients: Age 18 to 29; meeting DSM IV criteria for BN | Exercise: 2 hr introduction meeting, followed by 1-hr wkly session (45 minute aerobic, 15 minutes cool down) with fitness instructor; participants advised to exercise independently 2/wk at least 35 minutes | | Fair | G1: NR | Post-Treatment: | | | G1: 21.0 (2.0) | BMI, kg/m^2^, mean (SD):
Setting: | | G2: CBT (N = 16) | G2: 22 (2.7) | Healthy controls: not meeting BN inclusion criteria; eumenorrhea; regular participation in wt. bearing exercise (1–2 hrs/wk); no use of meds; willingness to complete fitness test, dietary registration, med exam, and 4 interviews | CBT: wkly 2-hr group sessions, following modified Hsu et al. (1991) protocol (Martinsen et al., 1990). | | Intent to treat: | G2: NR | G1: NR | | | G2: 20.0 (1.9) | G1: NR
Outpatient Oslo, Norway | | G3: Nutrition (N = 17) | G3: 22 (2.9) | Exclusion: | Nutrition Counseling: 2-hr group sessions, 2/wk in the first 2 wks, wkly thereafter, and held by a RD; tx modified from Hsu et al. (1992) protocol to include food log discussions and wt monitoring bi-wkly. | | No | G3: NR | G2: NR | | | G3: 21.0 (2.1) | G2: NR
Enrollment period: | | G4: Waitlist (N = 16) | G4: 23 (3.2) | Hx of AN or other psychiatric or somatic disorders; tx of EDs in previous 6 mos; current use of meds. | For G2 and G3, wt change >2kg was addressed by additional meal planning; participants were assigned 90 m/wk of homework and food logs. | | Blinding: | G4: NR | G3: NR | | | G4: 22.0 (2.5) | G3: NR
NR | | G5: Healthy Control (N = 13) | G5: 22 (4.1) | | BN sx (using EDI-II), physical activity, peak oxygen uptake, nutritional habits, and % body fat assessed at baseline, post-tx, 6- and 18-mos FU. | | NR | G2 vs G1 (P = NS) | Diff over time (P = NR) | | | G5: 21.0 (1.9) | G4: NR
| | Enrollment: | (P = NS) | | | | Adverse events: | All other comparisons (P = NR) | Diff between groups (P = NS) | | | (P = NS) | G5: NR
| | 77 ED patients recruited by letter from private practice, ED clinics | Sex: | | | | 1 injury in G1 | | Diff between groups in change over time (P = NR) | | | | (P = NS)
| | - 10 ineligible; - 3 declined; - 64 randomized | Female: 100% | | | | Funding: | | 6-mo FU: | | | % Body fat, mean (SD): | % Body fat, mean (SD):
| | 24 healthy participants recruited via college newspaper ads; 8 excluded | Race/ethnicity: | | | | NR | | G1: 11.86 (4.33) (P = NR) | | | G1: 24.1 (8.3) | G1: 21.5 (6.4) (P < 0.001)
| | - ED symptoms (3); - menstrual irregularity (2); - vegetarian diet (2); - competitive running (1) | NR | | | | | | G2: 7.15 (2.41) (P = NR) | | | G2: 23.4 (8.1) | G2: NR
| | Drop Outs | BN Duration, yrs, mean (SD): | | | | | | G3: NR | | | G3: 23.7 (8.9) | G3: NR
| | G1: (3) | G1: 7 (3.7) | | | | | | Diff over time (P = NR) | | | G4: 21.6 (5.1) | G4: NR
| | G2: (2) | G2: 5 (1.6) | | | | | | Diff between groups (P = 0.02) | | | G5: 25.5 (7.0) | G5: NR
| | G4: (1) | G3: 5 (2.3) | | | | | | G1 better than G2 | | | (P = NS) | Diff between groups (P = NR)
| | | G4: 6 (3.8) | | | | | | Diff between groups in change over time (P = NR) | | | | Diff between groups in change over time (P = NR)
| | | G5: NA | | | | | | 18-mo FU: | | | Fat mass, mean (SD): | 18-mo FU:
| | | (P = NS) | | | | | | G1: 13.43 (4.83) (P = NR) | | | G1: 21.5 (6.4) | Fat mass, mean (SD):
| | | Wkly Exercise, hrs, mean (SD): | | | | | | G2: 6.08 (4.65) (P = NR) | | | G2: NR | G1: 19.8 (4.89)
| | | G1: 2.5 (3.8) | | | | | | G3: NR | | | G3: NR | Diff between groups (P = 0.034)
| | | G2: 2.1 (2.4) | | | | | | Diff over time (P = NR) | | | G4: NR | Diff between groups (P = NR)
| | | G3: 2.5 (2.2) | | | | | | Diff between groups (P = 0.000) | | | G5: NR | Diff between groups in change over time (P = NR)
| | | G4: 3.1 (1.7) | | | | | | G1 better than G2 | | | (P = NS)
| | | G5: 1.8 (1.3) | | | | | | Diff between groups in change over time (P = NR) | | | Peak O2 uptake, mL/kg/min, mean (SD): | Peak O2 uptake, mL/kg/min, mean (SD):
| | | (P = NS) | | | | | EDI Bulimia, mean (SD): | EDI Bulimia, mean (SD): | | | G1: 43.5 (7.3) | NR
| | | | | | | | G1: NR | Post-Treatment: | | | G2: 42.0 (6.0)
| | | | | | | | G2: NR | G1: NR | | | G3: 44.1 (6.2)
| | | | | | | | G3: NR | G2: NR | | | G4: 41.3 (12.2)
| | | | | | | | G4: NR | G3: NR | | | G5: 43.1 (7.2)
| | | | | | | | (P = NR) | Diff over time (P = NR) | | | (P = NS)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 6-mo FU
| | | | | | | | | G1: NR
| | | | | | | | | G2: 2.64 (1.6) (P = NR)
| | | | | | | | | G3: 5.00 (3.1) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = 0.02)
| | | | | | | | | G2 better than G3
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 18-mo FU
| | | | | | | | | G1: NR
| | | | | | | | | G2: 2.14 (1.83) (P = NR)
| | | | | | | | | G3: 8.47 (2.15) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P < 0.000)
| | | | | | | | | G2 better than G3
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDI Body Dissatisfaction, mean (SD): | EDI Body Dissatisfaction, mean (SD):
| | | | | | | | NR | Post-Treatment:
| | | | | | | | (P = NR) | G1: NR
| | | | | | | | | G2: 9.64 (4.86) (P = NR)
| | | | | | | | | G3: 14.24 (5.53) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P < 0.02)
| | | | | | | | | G2 better than G3
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 6-mo FU
| | | | | | | | | G1: NR
| | | | | | | | | G2: 9.21 (3.02) (P = NR)
| | | | | | | | | G3: 14.00 (5.32) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P < 0.006)
| | | | | | | | | G2 better than G3
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 18-mo FU:
| | | | | | | | | G1: NR
| | | | | | | | | G2: 10.71 (3.45) (P = NR)
| | | | | | | | | G3: 12.71 (5.58) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Binge Episodes/wk, mean (SD): | Binge Episodes/wk, mean (SD):
| | | | | | | | G1: 7.3 (2.72) | Post-Treatment:
| | | | | | | | G2: 7.9 (2.95) | G1: NR
| | | | | | | | G3: 7.7 (3.76) | G2: NR
| | | | | | | | G4: 5.4 (2.63) | G3: NR
| | | | | | | | (P = NS) | G4: NR
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 6-mo FU:
| | | | | | | | | G1: NR
| | | | | | | | | G2: NR
| | | | | | | | | G3: NR
| | | | | | | | | G4: NR
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 18-mo FU:
| | | | | | | | | G1: 1.7 (2.87) (P = 0.002)
| | | | | | | | | G2: 4.4 (3.37) (P = 0.009)
| | | | | | | | | G3: 6.8 (3.67) (P = NS)
| | | | | | | | | G4: 4.5 (2.33) (P = NS)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = 0.04)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Vomiting Episodes/wk, mean (SD): | Vomiting Episodes/wk, mean (SD):
| | | | | | | | G1: 7.8 (3.39) | Post-tx:
| | | | | | | | G2: 8.6 (4.68) | G1: NR
| | | | | | | | G3: 8.2 (4.34) | G2: NR
| | | | | | | | G4: 5.6 (3.15) | G3: NR
| | | | | | | | (P = NS) | G4: NR
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 6-mo FU:
| | | | | | | | | G1: NR
| | | | | | | | | G2: 3.50 (2.93) (P = NR)
| | | | | | | | | G3: 7.06 (4.16) (P = NR)
| | | | | | | | | G4: NR
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P < 0.01)
| | | | | | | | | G2 better than G3
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 18-mo FU:
| | | | | | | | | G1: 2.4 (2.39) (P = 0.001)
| | | | | | | | | G2: 2.7 (1.94) (P = 0.003)
| | | | | | | | | G3: 7.2 (4.05) (P = NS)
| | | | | | | | | G4: 5.1 (2.47) (P = NS)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between G2 and G3 (P < 0.001)
| | | | | | | | | G2 better than G3
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Laxative Use, episodes/wk, mean (SD): | Laxative Use, episodes/wk, mean (SD):
| | | | | | | | NR | Post-tx:
| | | | | | | | (P = NR) | G1: 0.85 (0.99) (P = NR)
| | | | | | | | | G2: 2.1 (1.7) (P = NR)
| | | | | | | | | G3: NR
| | | | | | | | | G4: NR
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P < 0.02)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 6-mo FU:
| | | | | | | | | G1: 0.00 (0.00) (P = NR)
| | | | | | | | | G2: 2.57 (2.10) (P = NR)
| | | | | | | | | G3: NR
| | | | | | | | | G4: NR
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = 0.000)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 18-mo FU:
| | | | | | | | | G1: 0.08 (0.28) (P = NR)
| | | | | | | | | G2: 3.10 (2.40) (P = NR)
| | | | | | | | | G3: NR
| | | | | | | | | G4: NR
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P < 0.000)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 18-mo FU:
| | | | | | | | | 62% G1 (N = 8) had recovered from BN, and one subject met EDNOS criteria
| | | | | | | | | 36% G2 (N = 5) had recovered from BN, 2 met EDNOS criteria
| | | | | | | | | 24% G3 (N = 4) met EDNOS criteria
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | 8 consecutive wkly 60-minutes individual sessions by one of two master's level therapists. BT participants: a behavioral eating habit control program that was modified to focus on reducing binge eating and purging. Participants were given self-monitoring forms to monitor daily caloric intake, binge eating and purging but not instructed to self-monitor cognitions. CBT, abbreviated version of Fairburn's (1985) manual used. Self-monitoring included daily caloric intake, binge purge behavior and cognitions. Within therapy, dysfunctional beliefs and distorted cognitions were addressed and assertiveness, problem solving skill building and relaxation taught. Nonspecific self-monitoring group: provided with rationale on the value of insight development and resolution of intrapsychic conflicts through self-knowledge, given self-monitoring forms and asked to numerically indicate total binge-purge episodes on a daily basis and estimate daily caloric intake. At all subsequent sessions, self-monitoring forms collected and reviewed by the therapist and the therapist presented didactic information about early childhood experiences and participants discussed the material relative to themselves. The main diff between the BT, CBT and the NSMT group was the emphasis on self-control of the participants via active participation in BT and CBT. | ANOVAs to look at pre-tx diff among groups, expectancy ratings and therapist ratings. For the dependent variables of binge purge frequency, a 3 (time) x 3 (group) ANOVA was done. A Chi-square analysis to examine percentage of abstinence between groups. MANOVA's: to measure EDI. | Score: | Binge-purge episodes/wk, mean (SD): | Binge-purge episodes/wk, mean (SD): | BDI, mean (SD): | BDI, mean (SD): | | % IBW:
Thackwray et al., 1993 | Comparison of BT, CBT, and NSMT for BN | G1: CBT (N = NR) | 31.3 yrs (10.41) | Female, BN criteria from DSM III-R. | | | Poor | G1: 5.4 (3.0) | Post-tx: | G1: 25.5 (7.0) | Post-tx: | | Post-tx:
Setting: | | G2: BT (N = NR) | Sex: | Exclusion: | | | Intent to treat: | G2: 5.6 (4.0) | G1: 0.6 (1.0) (P < 0.01) | G2: 22.8 (14.0) | G1: 10.8 (12.0) (P = NR) | | G1: NR
Outpatient, USA | | G3: NSMT (N = NR) | Female:100% | Prior dx or current involvement in tx for BN and medical conditions, such as pregnancy or severe renal or cardiac problems | | | NR | G3: 5.6 (3.0) | G2: 0.0 (0.0) (P < 0.01) | G3: 28.1 (10.0) | G2: 6.5 (9.0) (P = NR) | | G2: NR
Enrollment period: | | Enrollment: | Race/ethnicity: | | | | Blinding: | (P = NS) | G3: 1.0 (3.0) (P < 0.01) | (P = NS) | G3: 16.1 (11.0) (P = NR) | | G3: NR
NR | | - Respondents to ads were screened on the phone; - 65 applicants were seen for a screening interview; - 47 met criteria for BN and were eligible for the study; - 47 were randomly assigned to one of three groups; - 39 completed tx and the 6-mo FU assessment | NR | | | | NA | | 6-mo FU: | | 6-mo FU: | | 6-mo FU:
| | | Duration of BN, yrs, mean (SD): | | | | Adverse events: | | G1: 0.4 (0.5) change from post-tx (P = NS) | | G1: 7.2 (7.0) (P = NR) | | G1: NR
| | | 6.7 (7.28) | | | | NR | | G2: 0.6 (0.5) change from post-tx (P = NS) | | G2: 9.6 (8.0) (P = NR) | | G2: NR
| | | Employed full-time | | | | Funding: | | G3: 2.7 (2.0) change from post-tx (P < 0.01) | | G3: 19.3 (12.0) (P = NR) | | G3: NR
| | | 75% | | | | NR | | Diff over time (P < 0.0001) | | Diff over time (P = NR) | | Diff over time (P < 0.001)
| | | Full or part-time students: | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NR) | | Diff between groups (P = NS)
| | | 19% | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P < 0.02) | | Diff between groups in change over time (P = NS)
| | | Homemakers: | | | | | EDI drive for thinness, mean (SD): | EDI drive for thinness, mean (SD): | | G1 better than G3 at 6-mo FU
| | | 16% | | | | | G1: 15.3 (5.0) | Post-tx:
| | | Mothers: | | | | | G2: 13.1 (5.0) | G1: 10.1 (6.0) (P = NR)
| | | 56% | | | | | G3: 13.8 (5.0) | G2: 4.3 (4.0) (P = NR)
| | | Lives with spouse: | | | | | (P = NS) | G3: 11.7 (5.0) (P = NR)
| | | 62% | | | | | | 6-mo FU:
| | | Lives with parents: | | | | | | G1: 8.3 (7.0) (P = NR)
| | | 18% | | | | | | G2: 4.9 (4.0) (P = NR)
| | | Lives with roommate: | | | | | | G3: 10.9 (6.0) (P = NR)
| | | 15% | | | | | | Diff over time (P = NR)
| | | Lives alone: | | | | | | Diff between groups (P = NR)
| | | 5% | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | G2 better than G1 and G3 at post-tx
| | | | | | | | | G2 better than G3 at FU
| | | | | | | | EDI Bulimia, mean (SD): | EDI Bulimia, mean (SD):
| | | | | | | | G1: 14.5 (5.0) | Post-tx:
| | | | | | | | G2: 12.3 (6.0) | G1: 5.5 (6.0) (P = NR)
| | | | | | | | G3: 11.0 (5.0) | G2: 2.5 (2.0) (P = NR)
| | | | | | | | (P = NS) | G3: 8.8 (7.0) (P = NS)
| | | | | | | | | 6-mo FU:
| | | | | | | | | G1: 2.9 (4.0) (P = NR)
| | | | | | | | | G2: 3.3 (3.0) (P = NR)
| | | | | | | | | G3: 7.8 (6.0) (P = NS)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.005)
| | | | | | | | | G2 better than G3 at post-tx
| | | | | | | | | G1 and G2 better than G3 at FU
| | | | | | | | | Abstinence, %:
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 92%
| | | | | | | | | G2: 100%
| | | | | | | | | G3: 69%
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G1 and G2 better than G3
| | | | | | | | | Maintained Abstinence at 6-mo FU:
| | | | | | | | | G1: 69%
| | | | | | | | | G2: 38%
| | | | | | | | | G3: 15%
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G1 better than G2 and G3
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | All interventions were manual based. MET was based on the manual, “Clinician's guide to getting better bit (e) by bit (e) (Schmidt and Treasure, 1997) while patients followed the workbook for this guide. For CBT, therapists followed the first four chapters of “Bulimia Nervosa: A guide to recovery” (Cooper, 1993) and patients were given monitoring sheets, meal planning, activity lists and problem solving activities. | Continuous data analyzed using t-tests, ANOVA or stepwise regression analyses. Dichotomous data were cross-tabulated. Repeated measures ANOVA's used to examine symptom diffs between wk 0 and wk 4 with tx group and pre-tx stage as between-group factors. | Score: | Binge frequency, mean (SD): | Binge frequency, mean (SD): | NR | NR | NR | NR
Treasure et al., 1999 | Explore relationship between patient's initial stage of change and symptom reduction, drop-out rate, and development of therapeutic alliance within context of CBT tx vs. MET tx. | G1: MET followed by Group CBT + MET followed by individual CBT (N = 48 + 39) | G1: 28.8 (7.8) | Dx of BN according to DSM IV | Tx in 3 phases -initial 4-wk phase of individual tx followed by 8 wks of either group or individual care and the last phase of moly FUs. | | Poor | G1: 5.0 (1.2) | G1: NR
Setting: | | G2: Individual CBT followed by Group CBT (N = 38) | G2: 28.5 (7.2) | Exclusion: | The three forms of tx:; 1) 4 wks of MET followed by 8 wks of group CBT; 2) 4 wks of individual CBT followed by group CBT for 8 wks; 3) 4 wks of MET followed by 8 wks of individual MET | | Intent to treat: | G2: 4.9 (1.1) | G2: NR
Eating Disorders Unit, Bethlem and Maudsley Hospital, UK | | Enrollment: | Sex: | Complicating features like diabetes mellitus; mixed cases of AN of binge purge subtype or EDNOS. | The two groups in which MET was first were combined to form G1. | | NR | (P = NS) | Diff over time (P < 0.001)
Enrollment period: | | - 142 consecutive female attenders at unit assessed; - 130 diagnosed with BN; - 5 excluded because of complicating features; - 12 were mixed cases AN (BP type) or EDNOS; - 125 BN participants randomized | Female 100% | | | | Blinding: | | Diff between groups (P = NS)
NR | | | Race/ethnicity: | | | | Participants blinded to stage of change that they fell into. | | Diff between groups in change over time (P = NR)
| | | NR | | | | Adverse events: | Vomiting frequency, mean (SD): | Vomiting frequency, mean (SD):
| | | BMI, kg/m ^ 2 ^ , mean (SD): | | | | NR | G1: 4.2 (1.9) | G1: NR
| | | G1: 24.0 (6.5) | | | | Funding: | G2: 4.4 (1.9) | G2: NR
| | | G2: 26.3 (9.3) | | | | NR | (P = NS) | Diff over time (P < 0.001)
| | | (P = NS) | | | | | | Diff between groups (P = NS)
| | | Duration of illness, yrs, mean (SD): | | | | | | Diff between groups in change over time (P = NR)
| | | G1: 10.8 (8.4) | | | | | Laxative use, mean (SD): | Laxative abuse, mean (SD):
| | | G2: 11.4 (6.4) | | | | | G1: 2.3 (1.9) | G1: NR
| | | Previous tx, %: | | | | | G2: 1.9 (1.7) | G2: NR
| | | G1: 62% | | | | | (P = NS) | Diff between groups (P = NS)
| | | G2: 62% | | | | | | Diff over time (P < 0.005)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Clinically sig improvement at 4 wks:
| | | | | | | | | Binge eating:
| | | | | | | | | G1: 53%
| | | | | | | | | G2: 68%
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | Symptoms by initial stage at wk 1: | Symptoms by initial stage:
| | | | | | | | Binge frequency, mean (SD): | Binge frequency, mean (SD):
| | | | | | | | Contemplation: | Contemplation:
| | | | | | | | G1: 4.7 (1.3) | G1: 3.8 (1.2) (P = NR)
| | | | | | | | G2: 4.8 (1.2) | G2: 3.2 (1.3) (P = NR)
| | | | | | | | (P = NR) | Action:
| | | | | | | | Action: | G1: 5.0 (1.4) (P = NR)
| | | | | | | | G1: 5.0 (1.4) | G2: 5.6 (0.9) (P = NR)
| | | | | | | | G2: 5.6 (0.9) | Diff between groups (P = NS)
| | | | | | | | (P = NR) | Diff between stages (P < 0.05)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Diff between stages in change over time (P = NR)
| | | | | | | | Vomiting frequency, mean (SD): | Clinically sig improvement at 4 wks:
| | | | | | | | Contemplation: | Vomiting:
| | | | | | | | G1: 3.9 (1.8) | G1: 58%
| | | | | | | | G2: 4.6 (2.0) | G2: 46%
| | | | | | | | (P = NR) | Diff between groups (P = NS)
| | | | | | | | Action: | Vomiting frequency, mean (SD):
| | | | | | | | G1: 3.5 (3.5) | Contemplation:
| | | | | | | | G2: 5.0 (2.2) | G1: 2.8 (1.6) (P = NR)
| | | | | | | | (P = NR) | G2: 3.1 (1.5) (P = NR)
| | | | | | | | | Action:
| | | | | | | | | G1: 2.0 (1.4) (P = NR)
| | | | | | | | | G2: 3.6 (1.7) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between stages (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Diff between stages in change over time (P = NR)
| | | | | | | | Laxative abuse, mean (SD): | Clinically sig improvement at 4 wks:
| | | | | | | | Contemplation: | Laxative use:
| | | | | | | | G1: 2.3 (1.7) | G1: 27%
| | | | | | | | G2: 2.0 (1.8) | G2: 13%
| | | | | | | | (P = NR) | Diff between groups (P = NS)
| | | | | | | | Action: | Laxative abuse, mean (SD):
| | | | | | | | G1: 2.5 (2.1) | Contemplation:
| | | | | | | | G2: 1.6 (1.3) | G1: 1.4 (1.1) (P = NR)
| | | | | | | | (P = NR) | G2: 1.7 (1.7) (P = NR)
| | | | | | | | | Action:
| | | | | | | | | G1: 0.0 (0.0) (P = NR)
| | | | | | | | | G2: 0.0 (0.0) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between stages (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Diff between stages in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | After 4 wk assessment, 6 mo study duration; TNR was prescribed a regular eating pattern; PNR involved learning to control appetite and wt based on understanding psychobiological cues. | Between and within group diffs evaluated using a two-way ANOVA corrected for repeated measures. | Score: | Data provided through graphic display only* | | NR | NR | NR | NR
Ventura and Bauer, 1999 | To examine nutritional rehabilitation-enhanced CBT focused on psychobiological reorganization of eating behaviors as compared to traditional CBT tx focused on the prescription of regular eating patterns in individuals with BN. | G1: PNR (N = 20) | G1: 24.1 (6.0) | DSM IV criteria for BN-purging type | In both groups, food diary used to record patterns of eating behavior, frequency of bingeing and/or vomiting; laxative misuse, excess exercise, carbohydrate and lipid intake; In G1, degree and duration of hunger, satiety, and differential satiety of macronutrients also recorded. | | Poor | Binge frequency (episodes/day), mean: | Binge frequency (episodes/day), mean:
Setting: | | G2: TNR (N = 20) | G2: 24.0 (5.6) | Exclusion: | In 1^st^ mo, diaries were discussed 1/wk, then bi-moly for the duration of the study. | | Intent to treat: | G1: ** | Post-tx:
Private practice outpatient unit, Verona, Italy | | Enrollment (N = 24): | Sex: | Failure to complete food diary (more than 5 days/mo or 2 wk-ends missing); requirement of hospitalization or refusal to participate | BMI, heart rate and blood pressure also taken at each visit. | | NR | G2: ** | G1: ** (P = NR)
Enrollment period: | | Completed: | Female: 100% | | | | Blinding: | (P = NS) | G2: ** (P = NR)
February to July, 1996 | | - 6-mo tx (N = 20); - 9-mo FU; - G1 = 19; - G2 = 15; - 12-mo FU; - G1 = 17; - G2 = 14 | Race/ethnicity: | | | | NA | | Diff between groups (P = 0.001)
| | | NR | | | | Adverse events: | | G1 better than G2
| | | BMI, kg/m^2^, mean (SD): | | | | NR | | Diff between groups in change over time (P = NR)
| | | G1: 21 (1.6) | | | | Funding: | | 3-mo FU:
| | | G2: 20.6 (1.5) | | | | NR | | G1: ** (P = NR)
| | | Duration of illness, yrs, mean (SD): | | | | | | G2: ** (P = NR)
| | | G1: 8.6 (4.9) | | | | | | Diff between groups (P = 0.001)
| | | G2: 6.5 (4.6) | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 6-mo FU:
| | | | | | | | | G1: ** (P = NR)
| | | | | | | | | G2: ** (P = NR)
| | | | | | | | | Diff between groups (P = 0.001)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Vomiting frequency (episodes/day), mean (SD): | Vomiting frequency (episodes/day), mean (SD):
| | | | | | | | G1: ** | Post-tx:
| | | | | | | | G2: ** | G1: ** (P = NR)
| | | | | | | | (P = NS) | G2: ** (P = NR)
| | | | | | | | | Diff between groups (P = 0.001)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 3-mo FU:
| | | | | | | | | G1: ** (P = NR)
| | | | | | | | | G2: ** (P = NR)
| | | | | | | | | Diff between groups (P = 0.001)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 6-mo FU:
| | | | | | | | | G1: ** (P = NR)
| | | | | | | | | G2: ** (P = NR)
| | | | | | | | | Diff between groups (P = 0.001)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Abstinence from purging at post-tx, N (%):
| | | | | | | | | G1: 18/20 (90%)
| | | | | | | | | G2: 2/20 (10%)
| | | | | | | | | (P = NR)
| | | | | | | | Data provided through graphic display only**
| | | | | | | | Carbohydrate Intake (servings/day), mean: | Post-tx:
| | | | | | | | G1: ** | Carbohydrate Intake (servings/day), mean:
| | | | | | | | G2: ** | G1: ** (P = NR)
| | | | | | | | (P = NS) | G2: ** (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.001)
| | | | | | | | | G1 higher than G2
| | | | | | | | | 9-mo FU:
| | | | | | | | | Carbohydrate Intake (servings/day), mean:
| | | | | | | | | G1: ** (P = NR)
| | | | | | | | | G2: ** (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 12-mo FU:
| | | | | | | | | Carbohydrate Intake (servings/day), mean:
| | | | | | | | | G1: ** (P = NR)
| | | | | | | | | G2: ** (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Lipid intake (olive oil servings/day), mean: | Post-tx:
| | | | | | | | G1: ** | Lipid intake (servings/day), mean:
| | | | | | | | G2: ** | G1: ** (P = NR)
| | | | | | | | (P = NR) | G2: ** (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.001)
| | | | | | | | | G1 higher than G2
| | | | | | | | | 9-mo FU:
| | | | | | | | | Lipid intake (servings/day), mean:
| | | | | | | | | G1: ** (P = NR)
| | | | | | | | | G2: ** (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.001)
| | | | | | | | | G1 higher than G2
| | | | | | | | | 12-mo FU:
| | | | | | | | | Lipid intake (servings/day), mean:
| | | | | | | | | G1: ** (P = NR)
| | | | | | | | | G2: ** (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.001)
| | | | | | | | | G1 higher than G2
| | | | | | | | | No diffs reported between G1 and G2 regarding number of meals ingested
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD) (range): | Inclusion: | Participants randomly assigned to group CBT, IPT or waitlist condition; G1 and G2 attended wkly 90 minutes group sessions for 16 wks; groups consisted of 9 members and 2 therapists, with 2 groups per tx condition. | At baseline and 16 wk post-tx, days of binge eating/wk, hunger, restraint, depression, interpersonal problems were assessed using repeated measures ANOVA. When sig interactions found, two-tailed Scheffe tests were used. When categorical measures compared, Chi-square test used. | Score: | Days binged in past wk, mean (SD): | Intent to treat analysis | BDI, mean (SD): | BDI, mean (SD): | Wt, kg, mean (SD) (range): | Change in wt, kg, mean:
Wilfley et al. 1993 | To assess the efficacy of group CBT and group IPT for binge eating in women with nonpurging BN. | G1: group CBT (N = 18) | 44.3 (8.3) (27–64) | Female; aged 18–65; met modified DSM III-R criteria for BN, including full requirements for binge behavior without purging behavior | CBT tx used Telch et al. (1990) manual and focused on eliminating BE, not wt reduction; IPT tx used Fairburn et al. (1991) manual for BN and focused on interpersonal relationships. | To assess change in binge behavior from baseline to 1 yr FU, paired t tests used. | Fair | G1: 4.2 (1.5) | Post-tx: | G1: 13.6 (8.1) | G1: 12.3 (6.8) (P = NR) | 87.3 (14.2) (60–117.5) | Post-tx: +2.0 kg
Setting: | | G2: group IPT (N = 18) | Sex: | Exclusion: | Waitlist had no contact with assessors during the 16 wk tx period. | | Intent to treat: | G2: 4.7 (1.8) | Days binged in past wk, mean (SD): | G2: 13.0 (7.5) | G2: 8.4 (6.7) (P = NR) | | G1: NR
Outpatient; Stanford University School of Medicine, USA | | G3: waitlist control (N = 20) | Female: 100% | Current of past hx of self-induced vomiting, laxative use or other purging behaviors; current use of antidepressants or appetite suppressants; concurrent tx for wt loss; concurrent DSM III-R dx or unipolar or bipolar affective disorder, psychosis, drug abuse, or alcoholism. | Including the 7-day calendar, binge eating recall method, the BDI, and Three Factor Eating Questionnaire, assessments were taken for all participants at baseline and 16 wk post-tx; participants in tx conditions were also assessed at 6 mo and 1yr FU | | Yes | G3: 4.4 (1.8) | G1: 2.2 (2.4) (P = NR) | G3: 14.6 (7.5) | G3: 14.2 (7.5) (P = NR) | | G2: NR
Enrollment period: | | Enrollment: | Race/ethnicity: | | | | Blinding: | (P = NS) | G2: 1.4 (1.7) (P = NR) | (P = NR) | Diff over time (P = NR) | | G3: NR
NR | | - 100 recruited via newspaper ads and screened; - 56 met criteria and participated; - 8 (22%) dropped out; attrition rates:G1: 33%, G2: 11% (P = NS) | White: 86% | | | | NA | | G3: 3.9 (1.7) (P = NR) | | Diff between groups (P = NS) | | Diff over time (P < 0.0007)
| | | AA: 5% | | | | Adverse events: | | Diff over time (P < 0.0001) | | Diff between groups in change over time (P = NS) | | Diff between groups (P = NR)
| | | Hispanic: 5% | | | | 2 dropped out of tx due to illness | | Diff between groups (P = NR) | | | | Diff between groups in change over time (P = NR)
| | | Pacific Islander: 2% | | | | Funding: | | Diff between groups in change over time (P < 0.0003) | RSE, mean (SD): | RSE, mean (SD): | | FU:
| | | Indian: 2% | | | | NIMH | | G1 and G2 better than G3 (P = NR) | G1: 3.1 (1.7) | G1: 2.8 (1.4) (P = NR) | | G1: no change
| | | Age of onset of bingeing, yrs, mean (SD) (range): | | | | | | G1 vs. G2 (P = NS) | G2: 3.3 (1.5) | G2: 2.4 (1.3) (P = NR) | | G2: - 3kg
| | | 20.4 (12.4) (3–44) | | | | | | Reduction of bingeing: | G3: 2.8 (1.2) | G3: 3.0 (1.5) (P = NR) | | G3: NR
| | | Duration of binge eating, yrs, mean (SD) (range): | | | | | | G1: 48% | (P = NR) | Diff over time (P = NS) | | Diff over time (P < 0.03)
| | | 23.7 (13.4) (2–53) | | | | | | G2: 71% | | Diff between groups (P = NS) | | Diff between groups (P = NR)
| | | BMI, kg/m^2^, mean (SD) (range): | | | | | | G3: 10% | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | 32.8 (5.2) (22.3–43.8) | | | | | | % Abstinent: | Inventory of Interpersonal Problems, mean (SD): | Inventory of Interpersonal Problems, mean (SD):
| | | Civil Status: | | | | | | G1: 28% | G1: 1.6 (0.5) | G1: 1.4 (0.5) (P = NR)
| | | Never married: 10.7% | | | | | | G2: 44% | G2: 1.7 (0.7) | G2: 1.2 (0.6) (P = NR)
| | | Married: 58.9% | | | | | | G3: 0% | G3: 1.4 (0.5) | G3: 1.2 (0.6) (P = NR)
| | | Divorced: 28.6% | | | | | TFEQ-Disinhibition, mean (SD): | TFEQ-Disinhibition, mean (SD): | (P = NR) | Diff over time (P = NR)
| | | Separated: 1.8% | | | | | G1: 14.1 (1.8) | G1: 13.1 (2.4) (P = NR) | | Diff between groups (P = NS)
| | | Education/Employment: | | | | | G2: 14.2 (1.2) | G2: 12.4 (2.8) (P = NR) | | Diff between groups in change over time (P = NS)
| | | College grad: 38% | | | | | G3: 15.0 (0.94) | G3: 14.9 (1.0) (P = NR)
| | | Some college: 50% | | | | | (P = NR) | Diff over time (P = NR)
| | | HS grad or less: 12% | | | | | | Diff between groups (P = NR)
| | | Employed: 73% | | | | | | Diff between groups in change over time (P = 0.02)
| | | | | | | | | G1 vs. G3 (P < 0.02)
| | | | | | | | | G1 better than G3
| | | | | | | | | G2 vs. G3 (P < 0.01)
| | | | | | | | | G2 better than G3
| | | | | | | | | G1 vs. G2 (P = NS)
| | | | | | | | TFEQ-Hunger, mean (SD): | TFEQ-Hunger, mean (SD):
| | | | | | | | G1: 10.2 (2.0) | G1: 9.2 (2.8) (P = NR)
| | | | | | | | G2: 10.5 (2.8) | G2: 7.8 (4.8) (P = NR)
| | | | | | | | G3: 9.9 (3.3) | G3: 9.2 (3.4) (P = NR)
| | | | | | | | (P = NR) | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | TFEQ-Restraint, mean (SD): | TFEQ-Restraint, mean (SD):
| | | | | | | | G1: 7.3 (3.8) | G1: 9.3 (3.6) (P = NR)
| | | | | | | | G2: 7.3 (3.2) | G2: 11.0 (5.6) (P = NR)
| | | | | | | | G3: 8.2 (3.4) | G3: 8.6 (3.7) (P = NR)
| | | | | | | | (P = NR) | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = 0.03)
| | | | | | | | | G2 vs. G3 (P = 0.02)
| | | | | | | | | G2 better than G3
| | | | | | | | | G1 vs. G2 (P = NS)
| | | | | | | | | FU:
| | | | | | | | | Change in binge frequency (days in past wk) from baseline, mean (SD):
| | | | | | | | | G1: -2.4 (P < 0.003)
| | | | | | | | | G2: -2.0 (P < 0.001)
| | | | | | | | | G3: NR
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Binge frequency from 16wk post-tx to 1yr FU increased in both groups (P < 0.05)
| | | | | | | | | Completers-only (G1: N = 10; G2: N = 13)
| | | | | | | | | Post-tx:
| | | | | | | | | Binge reduction, %:
| | | | | | | | | G1: 64%
| | | | | | | | | G2: 68%
| | | | | | | | | G3: 11%
| | | | | | | | | FU:
| | | | | | | | | Binge reduction, %:
| | | | | | | | | G1: 55%
| | | | | | | | | G2: 50%
| | | | | | | | | G3: NR
| | | | | | | | | Change in binge frequency (days in past wk), mean (SD):
| | | | | | | | | G1: -2.1 (P < 0.04)
| | | | | | | | | G2: -2.4 (P < 0.02)
| | | | | | | | | G3: NR
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Binge frequency from 16wk post-tx to 1yr FU increased in both groups (P < 0.005)
Author, yr: | Research objective: | Groups (N = 110): | Age, yrs, mean (SD): | Inclusion: | 19 sessions of CBT or IPT; CBT focused on shape, wt, and eating behaviors, IPT focused on non-eating/wt-related personal issues; tx was conducted by doctoral level psychologist or psychiatrist. | Associations between stages of change at baseline and categorical measures of outcome examined using chi-square tests. | Score: | | Completer Analysis (N = 66): | NR | NR | NR | NR
Wolk and Devlin, 2001 | To test the hypothesis that the stage of change is a useful predictor of dropout and related to tx outcome in individuals in brief psychotherapy for BN. | G1: CBT | G1: 28.3 (7.0) | DSM III-R criteria for BN, dx using SCID | Prior to tx, Stage of Change scale used to predict outcome among randomized participants. | | Good | | Stage of change as a predictor of outcome (remittance):
Companion article: | | G2: IPT | G2: 27.9 (7.5) | Exclusion: | Readiness to change assessed using an algorithm of the relationship between stages of change and tx response | | Intent to treat: | | Χ^2^ = 12.29 (P = 0.02), 0/10 “precontemplators” remitted at end of tx
Agras et al., 2000 | | Sample from one site in Agras, Walsh et al. (2000) multicenter study | (P = NS) | Severe physical or psychiatric condition that would interfere with tx; current AN; current psychotherapeutic tx of any type; all psychotropic meds; pregnancy; having received an adequate trial of CBT or IBT for BN prior to study | | | No | | Stage of change as a predictor of improvement (undefined):
Setting: | | Enrollment: | Sex: | | | | Blinding: | | G1: Χ^2^ = 3.09 (P = NS)
ED Unit, New York State Psychiatric Institute at Columbia Medical Center, NY, NY, USA | | - 129 screened; - 110 randomized; - 66 completed tx (G1 = 32, G2 = 34; full BN remission = 14; subthreshold BN = 34; full BN = 18) | Female: NR | | | | NA | | G2: Χ^2^ = 12.11 (P = 0.02)
Enrollment period: | | | Race/ethnicity N (%): | | | | Adverse events:
NR | | | White: | | | | 9 withdrawn from tx, 8 of which received meds: 7 for severe depression, 1 for an acute onset of panic disorder
| | | G1: 87 (79) | | | | Funding:
| | | G2: 81 (74) | | | | NR
| | | (P = NR)
| | | Hispanic:
| | | G1: 11 (10)
| | | G2: 14 (13)
| | | (P = NR)
| | | African American:
| | | G1: 7 (6)
| | | G2: 7 (6)
| | | (P = NR)
| | | Asian:
| | | G1: 4 (4)
| | | G2: 7 (6)
| | | (P = NR)
| | | American Indian:
| | | G1: 1 (1)
| | | G2: 0 (0)
| | | (P = NR)

Evidence Table 8. Self-help trials for bulimia nervosa

| | | | | | | | Eating Related Measures | | Psychological/Psychiatric Measures | | Biomarkers
Study Description | Objective | Design | Patient Characteristics | Inclusion/Exclusion Criteria | Treatment | Statistical Methods | Quality | Baseline | Outcomes | Baseline | Outcomes | Baseline | Outcomes
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Upon enrollment, individuals randomized to G1 or G2; G1: self-help manual, self-paced over 18 wks, and offered 18, 20 minutes wkly visits, as needed; G2: 18 wkly, 90 minute sessions with 8–12 participants using a CBT manual (based on Fairburn, 1985, and Agras, 1987) for BN; attendance at 50% (9 sessions) defined tx completion. | One-way ANCOVAs compared the two tx at all timepoints); when post-tx data missing, pre-tx values substituted; mixed-effects linear regression analyses performed to compare changes in outcome over time by tx condition, controlling for baseline values. | Score: | Results from the primary, intent-to-treat analysis (N = 81), unless specified. | Mid-tx, Post-tx, FU (N = 55) | BDI, mean (SD): | BDI, mean (SD): | BMI, mean (SD): | BMI, mean (SD):
Bailer et al., 2004 | To evaluate the short and long-term efficacy of an 18 wk guided self-help program versus group CBT in the tx of patients with BN. | G1: Self-help (N = 40) | G1: 23.3 (4.1) | Age 17 and above; DSM IV criteria for BN | BN behavior self-monitored with EB-IV; EDQ, EDI, BDI, ht, wt, and vital signs, assessed at baseline, mid-tx (10 wks), and tx-end (18wks), and 1 yr FU. | | Fair | Binge Frequency, 4 wks, mean (SD): | Binge Frequency, 4 wks, mean (SD): | G1: 15.55 (9.98) | Mid-tx: | G1: 21.68 (3.15) | Mid-tx:
Setting: | | G2: CBT (N = 41) | G2: 24.2 (4.9) | Exclusion: | | | Intent to treat: | G1: 26.15 (21.51) | Mid-tx: | G2: 17.75 (11.41) | G1: 9.61 (9.59) (P = NR) | G2: 20.69 (2.44) | G1: 21.61 (2.25) (P = NR)
Outpatient ED clinic, Department of General Psychiatry, University Hospital of Psychiatry, Vienna, Austria | | Enrollment: | (P = NS) | Medically unstable or of severe suicide risk; unstable dosage of meds for BN over 3 mos prior to study | | | Yes, for primary analysis | G2: 27.95 (29.66) | G1: 12.74 (12.90) | (P = NR) | G2: 13.64 (11.29) (P = NR) | (P = NR) | G2: 20.94 (2.04) (P = NR)
Enrollment period: NR | | - 87 recruited via therapist or self-referral to ED clinic; - 81 randomized (6 refused to participated for reasons NR); - G1: 30 (75%) completed tx; 25 (62.5%) completed 1 yr FU; - G2: 26 (63.4%) completed tx; 30 (73.1%), including 5 drop-outs, completed FU; - Overall dropout rate: 30.8%; Drop out rate between groups was not sig: G1: 25%; G2: 36.6%. | Age at onset, yrs, mean (SD): | | | | Blinding: | (P = NR) | G2: 14.10 (16.03) | | Post-tx: | | Post-tx:
| | | G1: 17.3 (2.3) | | | | No | | (P = NR) | | G1: 8.27 (8.33) (P = NR) | | G1: 21.73 (2.28) (P = NR)
| | | G2: 17.7 (3.2) | | | | Adverse events: | | Post-tx: | | G2: 13.83 (11.48) (P = NR) | | G2: 20.74 (2.23) (P = NR)
| | | (P = NS) | | | | Except for 2 patients who moved, all other drop-outs either openly refused to participate (reasons: NR), or cancelled appts. | | G1: 7.67 (9.06) (P = NR) | | Diff over time (P < 0.001) | | Diff over time (P = NS)
| | | Sex: | | | | Funding: | | G2: 16.31 (23.65) (P = NR) | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | Female: NR | | | | Grant from the Osterreichische Nationalbank (Jubilaumsfonds Grant 6360) | | Diff over time (P < 0.001) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | Race/ethnicity: | | | | | | Diff between groups (P = NS) | | 1yr FU: | | 1yr FU:
| | | NR | | | | | | Diff between groups in change over time (P = NS) | | G1: 7.61 (6.30) (P = NR) | | G1: 22.00 (2.25) (P = NR)
| | | BMI, kg/m ^ 2 ^ , mean (SD): | | | | | | 1-yr FU: | | G2: 11.70 (12.99) (P = NR) | | G2: 20.45 (2.94) (P = NR)
| | | G1: 21.7 (3.1) | | | | | | G1: 7.54 (13.15) (P = NR) | | Diff over time (P = NS) | | Diff over time (P = NS)
| | | G2: 20.7 (2.4) | | | | | | G2: 13.11 (21.76) (P = NR) | | Diff between groups (P = 0.05) | | Diff between groups (P = 0.02)
| | | (P = NS) | | | | | | Diff over time (P = NS) | | G1 better than G2 | | G2 better than G1
| | | Nonpurger, N (%): | | | | | | Diff between groups (P = NS) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | G1: 5 (12.5) | | | | | | Diff between groups in change over time (P = NS)
| | | G2: 4 (9.7) | | | | | Vomiting frequency (N = 64), 4 wks, mean (SD): | Vomiting frequency, 4 wks, mean (SD):
| | | (P = NS) | | | | | G1: 21.2 (22.8) | Mid-tx:
| | | Meds, SSRIs, N (%): | | | | | G2: 30.4 (32.8) | G1: 9.78 (13.04) (P = NR)
| | | G1: 6 (15) | | | | | (P = NR) | G2: 14.76 (18.59) (P = NR)
| | | G2: 14 (34.1) | | | | | | Post-tx:
| | | (P = 0.046) | | | | | | G1: 6.00 (7.07) (P = NR)
| | | Lifetime AN, N (%): | | | | | | G2: 15.50 (23.99) (P = NR)
| | | G1: 9 (22.5) | | | | | | Diff over time (P < 0.001)
| | | G2: 17 (41.4) | | | | | | Diff between groups (P = NS)
| | | (P = NS) | | | | | | Diff between groups in change over time (P = NS)
| | | Lifetime major depression, N (%): | | | | | | 1-yr FU (N = 55):
| | | G1: 12 (30) | | | | | | G1: 4.62 (13.15) (P = NR)
| | | G2: 24 (58.5) | | | | | | G2: 11.89 (22.24) (P = NR)
| | | (P = 0.009) | | | | | | Diff over time (P = NS)
| | | Current major depression, N (%): | | | | | | Diff between groups (P = 0.04)
| | | G1: 2 (5) | | | | | | G1 better than G2
| | | G2: 11 (26.8) | | | | | | Diff between groups in change over time (P = NS)
| | | (P = 0.008) | | | | | Laxative use, mean (SD): | Laxative use, mean (SD):
| | | Self-mutilation, N (%): | | | | | G1: 5.08 (14.86) | Mid-tx:
| | | G1: 15 (37.5) | | | | | G2: 4.03 (8.08) | G1: 0.19 (0.68) (P = NR)
| | | G2: 10 (24.3) | | | | | (P = NR) | G2: 3.33 (7.47) (P = NR)
| | | (P = NS) | | | | | | Post-tx:
| | | Suicide attempts, N (%): | | | | | | G1: 0.33 (1.47) (P = NR)
| | | G1: 2 (5) | | | | | | G2: 3.73 (8.75) (P = NR)
| | | G2: 9 (21.9) | | | | | | Diff over time (P = 0.017)
| | | (P = 0.026) | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 1yr FU:
| | | | | | | | | G1: 0.08 (0.28) (P = NR)
| | | | | | | | | G2: 4.59 (10.15) (P = NR)
| | | | | | | | | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = 0.025)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDI-DT, mean (SD): | EDI-DT, mean (SD):
| | | | | | | | G1: 14.0 (5.9) (P = NR) | Mid-tx:
| | | | | | | | G2: 14.43 (5.16) (P = NR | G1: 8.39 (6.73) (P = NR)
| | | | | | | | | G2: 10.00 (6.81) (P = NR)
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 7.67 (6.53) (P = NR)
| | | | | | | | | G2: 10.87 (6.69) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 1yr FU:
| | | | | | | | | G1: 6.59 (5.97) (P = NR)
| | | | | | | | | G2: 5.21 (5.64) (P = NR)
| | | | | | | | | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = 0.009)
| | | | | | | | | G2 better than G1
| | | | | | | | EDI-B, mean (SD): | EDI-B, mean (SD):
| | | | | | | | G1: 10.38 (5.29) | Mid-tx:
| | | | | | | | G2: 10.25 (5.51) | G1: 4.32 (4.45) (P = NR)
| | | | | | | | (P = NR) | G2: 5.50 (4.86) (P = NR)
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 3.10 (4.34) (P = NR)
| | | | | | | | | G2: 6.57 (5.32) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = 0.01)
| | | | | | | | | G1 better than G2
| | | | | | | | | 1yr FU (N = 55):
| | | | | | | | | G1: 3.32 (5.18) (P = NR)
| | | | | | | | | G2: 4.50 (5.06) (P = NR)
| | | | | | | | | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = 0.018)
| | | | | | | | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDI-BD, mean (SD): | EDI-BD, mean (SD):
| | | | | | | | G1: 15.55 (8.47) | Mid-tx:
| | | | | | | | G2: 15.45 (7.60) | G1: 10.96 (8.92) (P = NR)
| | | | | | | | (P = NR) | G2: 14.68 (9.34) (P = NR)
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 9.97 (7.45) (P = NR)
| | | | | | | | | G2: 14.87 (8.07) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 1yr FU:
| | | | | | | | | G1: 10.18 (8.66) (P = NR)
| | | | | | | | | G2: 9.29 (9.42) (P = NR)
| | | | | | | | | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Meal Frequency, 4 wks, mean (SD): | Meal Frequency, mean (SD):
| | | | | | | | G1: 77.44 (43.57) | Mid-tx:
| | | | | | | | G2: 59.49 (29.56) | G1: 80.65 (47.41) (P = NR)
| | | | | | | | (P = NR) | G2: 68.84 (33.53) (P = NR)
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 72.76 (44.15) (P = NR)
| | | | | | | | | G2: 68.28 (26.13) (P = NR)
| | | | | | | | | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = 0.048)
| | | | | | | | | G1 greater than G2
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 1yr FU:
| | | | | | | | | G1: 62.36 (29.85) (P = NR)
| | | | | | | | | G2: 52.37 (28.89) (P = NR)
| | | | | | | | | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | “Recovered”, no binge or purge behavior for prior mo, N (%):
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 3 (7.5)
| | | | | | | | | G2: 5 (12.2)
| | | | | | | | | 1 yr FU:
| | | | | | | | | G1: 9 (22.5)
| | | | | | | | | G2: 6 (14.6)
| | | | | | | | | “Remitted”, binge or purge episodes < 2x/wk in prior mo, N (%):
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 16 (40)
| | | | | | | | | G2: 12 (29.3)
| | | | | | | | | 1 yr FU:
| | | | | | | | | G1: 20 (50)
| | | | | | | | | G2: 15 (36.6)
Author, yr: | Research objective: | Groups enrolled (N = 85): | Age, yrs, mean (SD), range: | Inclusion: | Pre-tx assessment using subscales of EDE and EDI, wt, ht, BDI, BAI, RSE, Inventory of Interpersonal Problems, Dimensional Assessment of Personality Pathology | ITT: 2 (Pre-and post-) x 3 (CBT vs. non-specific vs. waitlist) repeated measures ANOVA using pre-tx values carried forward for missing post-tx data. | Score: | Objective binge frequency, past 4 wks, median: | Objective binge frequency, past 4 wks, median: | BDI, mean (SD): | BDI, mean (SD): | | Decrease in Intense Exercise:
Carter, Olmsted, et al., 2003 | To examine the efficacy of a CBT self-help manual for tx of BN, and compare it to an “attention placebo-control” condition (i.e., non-specific self-help manual) to control for nonspecific factors. A secondary aim was to identify predictors of outcome. | G1: CBT-based self-help (N = 28) | 27 (8), 17–53 | EDE criteria for BN, met modified DSM IV binge/purge frequency criteria (1x/wk), seeking specialized tx for first time | Randomization and Instructions | Paired t-test, 1-way ANOVA, and between-group t-test post-hoc comparisons. | Fair | G1: 24.5 | G1: 10 (P = 0.006) | G1: 26.5 (11.4) | G1: 26.9 (10.5) (P = NR) | | G1(P = 0.01)
Setting: | | G2: Non-specific self-help (N = 28) | Sex: | Exclusion: | G1: 2-mo manualized CBT-based self-help program using ‘Overcoming Binge Eating’ (Fairburn, 1995). | Chi Square tests to compared proportions of responders. | Intent to treat: | G2: 18.5 | G2: 11.5 (P = 0.008) | G2: 24.4 (10.5) | G2: 21.2 (11.1) (P = NR) | | G2(P = NS)
Individuals on a waiting list for tx at a hospital-based specialty outpatient clinic, Toronto, Canada | | G3: Waitlist (N = 29) | Female, 100% | Age < 17 yrs, pregnant, medical illness known to influence wt, current or prior specialist tx for ED, BMI < 18 kg/m^2^ | G2: 2-mo manualized assertiveness skill-based self-help program using ‘Self-Assertion for Women’ (Butler, 1992). | | Yes | G3: 28.0 | G3: 27.0 (P = NS) | G3: 22.3 (10.0) | G3: 20.9 (14.3) (P = NR) | | G3(P = NS)
Enrollment period: | | Enrollment: | Race/ethnicity, %: | | G3: waitlist | | Blinding: | (P = NR) | Diff over time (P < 0.001) | (P = NR) | Diff over time (P = NS) | | Diff over time (P = NR)
NR | | Potential subjects referred | White: 83% | | Post-assessment (as above) + compliance measure | | No | | Diff between groups (P = NS) | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | Phone screen: 245 | Black: 25% | | | | Adverse events: | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = 0.04)
| | Invited for assessment interview: 123 | Asian: 7% | | | | none | | | | | | G1 better than G2, G3
| | Completed assessment: 89 | Other: 8% | | | | Funding: | Objective Purge frequency, past 4 wks, median: | Objective purge frequency, past 4 wks, median: | BAI, mean (SD): | BAI, mean (SD):
| | Randomized | Marital status, %: | | | | Dean's fund, Department of Medicine, University of Toronto | G1: 26.0 | G1: median = 22.5 (P = 0.04) | G1: 24.4 (12.0) | G1: 25.4 (12.3) (P = NR)
| | (N = 85) | Single: 71% | | | | | G2: 27.5 | G2: median = 16.5 (P = 0.005) | G2: 23.4 (12.8) | G2: 21.5 (12.8) (P = NR)
| | Drop-outs, N (%): | Partnered: 22% | | | | | G3: 46.5 | G3: median = 32.0 (P = NS) | G3: 21.5 (9.6) | G3: 19.6 (10.9) (P = NR)
| | G1: 5 (17.9%) | Divorced: 6% | | | | | (P = NR) | Diff over time (P = NR) | (P = NR) | Diff over time (P = NS)
| | G2: 7 (25%) | Widowed: 1% | | | | | G1, G2 lower than G3 | Diff between groups (P = NS) | | Diff between groups (P = NR)
| | G3: 8 (27.6%) | BMI, kg/m ^ 2 ^ , mean (SD), range: | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | (P = NS) | 23.0 (5.0), 18–41 | | | | | EDE Restraint, mean (SD): | EDE Restraint, mean (SD): | Inventory of Interpersonal Problems, mean (SD): | Inventory of Interpersonal Problems, mean (SD):
| | Completers, N: | BN Subtype: | | | | | G1: 4.1 (1.3) | G1: 3.9 (1.5) (P = NR) | G1: 1.9 (0.6) | G1: 2.0 (0.7) (P = NR)
| | G1: 23 | 93% purging | | | | | G2: 3.7 (1.4) | G2: 3.6 (1.6) (P = NR) | G2: 1.9 (0.5) | G2: 1.6 (0.6) (P = NR)
| | G2: 21 | BN Onset, yrs, mean (SD), range: | | | | | G3: 3.8 (1.7) | G3: 3.7 (1.5) (P = NR) | G3: 1.8 (0.6) | G3: 1.9 (0.6) (P = NR)
| | G3: 21 | 19 (6), 10–38 | | | | | (P = NR) | Diff over time (P = NS) | (P = NR) | Diff over time (P = NS)
| | | BN Duration, yrs, mean (SD), range: | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | 7 (6), 0.5–33 | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | Objective Binge Episodes, past 4 wks, mean (SD, range: | | | | | EDE Eating concern, mean (SD): | EDE Eating concern, mean (SD): | Knowledge of cognitive-behavioral psycho-educational content of tx manual, mean (SD): | Knowledge of cognitive-behavior psycho-educational content of tx manual, mean (SD):
| | | 28 (23), 4–112 | | | | | G1: 4.5 (1.1) | G1: 4.3 (1.0) (P = NR) | G1: 7.4 (2.7) | G1: 7.8 (2.7) (P = NR)
| | | Objective Purge Episodes, past 4 wks, mean (SD), range: | | | | | G2: 4.2 (1.3) | G2: 3.8 (1.2) (P = NR) | G2: 8.3 (2.6) | G2: 8.0 (2.7) (P = NR)
| | | 41 (35), 0–112 | | | | | G3: 4.1 (1.4) | G3: 3.8 (1.3) (P = NR) | G3: 7.6 (2.9) | G3: 8.1 (2.6) (P = NR)
| | | | | | | | (P = NR) | Diff over time (P = NS) | (P = NR) | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE Shape concern, mean (SD): | EDE Shape concern, mean (SD): | Knowledge of non-specific psychoeducational content of tx manual, mean (SD): | Knowledge of non-specific psychoeducational content of tx manual, mean (SD):
| | | | | | | | G1: 5.2 (1.1) | G1: 5.0 (1.2) (P = NR) | G1: 5.7 (1.8) | G1: 5.6 (2.2) (P = NR)
| | | | | | | | G2: 4.8 (1.3) | G2: 4.5 (1.3) (P = NR) | G2: 5.0 (1.7) | G2: 6.6 (2.2) (P = 0.005)
| | | | | | | | G3: 4.7 (1.3) | G3: 4.6 (1.3) (P = NR) | G3: 4.7 (2.1) | G3: 5.0 (2.3) (P = NR)
| | | | | | | | (P = NR) | Diff over time (P = NS) | (P = NR) | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = 0.02)
| | | | | | | | | | | G2 better than G1, G3
| | | | | | | | EDE Wt concern, mean (SD): | EDE Wt concern, mean (SD): | | Responders, decrease of at least 50% bingeing or purging, N (%):
| | | | | | | | G1: 4.9 (1.2) | G1: 4.6 (1.2) (P = NR) | | G1: 15 (53.6%)
| | | | | | | | G2: 4.3 (1.4) | G2: 4.0 (1.3) (P = NR) | | G2: 14 (50.0%)
| | | | | | | | G3: 3.9 (1.6) | G3: 4.0 (1.4) (P = NR) | | G3: 9 (31.0%)
| | | | | | | | (P = NR) | Diff over time (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups (P = NR) | | Compared to non-responders, responders had higher perfectionism (P = 0.03), higher compulsivity (P = 0.04), higher intimacy problems (P = 0.02), and lower CBT knowledge (P = 0.03)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | Compliance, amount of manual read, %:
| | | | | | | | | | | G1: 78%
| | | | | | | | | | | G2: 59%
| | | | | | | | | | | (P = NS)
| | | | | | | | | | | Compliance, completed behavioral exercises, %:
| | | | | | | | | | | G1: 28.6%
| | | | | | | | | | | G2: 21.4%
| | | | | | | | | | | (P = NS)
| | | | | | | | | | | Predictors of compliance included lower baseline knowledge about ED (P = 0.02), higher intimacy problems (P = 0.02), and higher compulsivity (P = 0.02).
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Participants in self-help tx used manual “Bulimia Nervosa: a guide to recovery (Cooper, 1993), and advised to work through it with regular contact with GP, who also received copy of the manual and guidelines for administration. | Repeated-measures MANOVA and MANCOVA conducted on BITE scores for two groups; Individual repeated measures analysis conducted to examine diff between BDI, EDE, and WLFL measures between groups. | Score: | BITE, mean (SD): | BITE, mean (SD): | BDI, mean (SD): | BDI, mean (SD):
Durand and King, 2003 | To assess the efficacy of a general practice-based, self-help tx versus specialist outpatient tx for women with BN. | G1: GP-supported self help (N = 34) | G1: 28.3 (6.5) | General practitioner referral; dx of BN (DSM IV); aged 18 or older; female; English speaking | Participants in specialist tx seen by clinical tx team in one of three clinics on wkly or fortnightly basis for as long as deemed appropriate by specialist caregiver. | Power calculations conducted based on BITE. | Fair | G1: 34.1 (6.3) | 6 mos: | G1: 27.7 (9.7) | 6 mos:
Setting: | | G2: Specialist tx (N = 34) | G2: 24.5 (5.2) | Exclusion: | Duration at clinician's discretion. | | Intent to treat: | G2: 33.7 (5.9) | G1: 28.9 (11.3) (P = NR) | G2: 21.4 (10.7) | G1: 17.8 (11.7) (P = NR)
Three outpatient specialist clinics, London, UK | | Enrollment: | (P = NR) | Requiring urgent clinic assessment; pregnancy; medical disorder such as diabetes; substance or alcohol misuse problems; suicidal intent | | | Yes | (P = NR) | G2: 28.2 (9.9) (P = NR) | (P = NR) | G2: 18.1 (10.6) (P = NR)
Enrollment period: | | 209 referrals | Sex: | | | | Blinding: | | 9 mos: | | 9 mos:
January 1995-June 1997 | | 68 (32.5%) randomized | Female: 100% | | | | NA | | G1: 26.2 (12.4) (P = NR) | | G1: 16.2 (9.9) (P = NR)
| | Completed tx, N (%): | Race/ethnicity: | | | | Adverse events: | | G2: 29.6 (11.4) (P = NR) | | G2: 15.5 (10.8) (P = NR)
| | G1: 34 (100%) | White: | | | | NR | | Diff over time (P < 0.001) | | Diff over time (P = 0.001)
| | G2: 26 (76%) | G1: 29 (85%) | | | | Funding: | | Diff between groups (P = NS) | | Diff between groups (P = NR)
| | Completed 6-mo FU, N (%): | G2: 30 (88%) | | | | North Thames Regional Health Authority | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NR)
| | G1: 22 (64.7%) | (P = NR) | | | | | | | | A direct relationship between BDI and BITE scores found (P = 0.001); as BDI scores decreased over time, so did BITE scores
| | G2: 28 (82.4%) | Black: | | | | | Objective bulimic episodes, past 28 days, mean (SD): | Objective bulimic episodes, past 28 days, mean (SD): | Patient-rated severity, mean (SD): | Patient-rated severity, mean (SD):
| | Completed 9-mo FU, N (%): | G1: 3 (9%) | | | | | G1: 19.0 (15.2) | 6 mos: | G1: 7.6 (2.2) | 6 mos:
| | G1: 26 (76.5%) | G2: 3 (9%) | | | | | G2: 20.4 (19.6) | G1: 16.4 (17.4) (P = NR) | G2: 7.1 (2.6) | G1: 6.6 (3.2) (P = NR)
| | G2: 28 (82.4%) | (P = NR) | | | | | (P = NR) | G2: 12.6 (14.2) (P = NR) | (P = NR) | G2: 6.1 (3.0) (P = NR)
| | | Other: | | | | | | 9 mos: | | 9 mos:
| | | G1: 1 (3%) | | | | | | G1: 15.0 (17.4) (P = NR) | | G1: 5.8 (3.1) (P = NR)
| | | G2: 1 (3%) | | | | | | G2: 14.9 (18.9) (P = NR) | | G2: 4.8 (2.8) (P = NR)
| | | (P = NR) | | | | | | Diff over time (P = NS) | | Diff over time (P = 0.001)
| | | Missing data: | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | G1: 1 (3%) | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | G2: 0 (0%) | | | | | Episodes of vomiting, past 28 days, mean (SD): | Episodes of vomiting, past 28 days, mean (SD):
| | | (P = NR) | | | | | G1: 35.1 (31.0) | 6 mos:
| | | Duration of Eating Problem, yrs, mean (SD): | | | | | G2: 37.8 (33.9) | G1: 25.0 (25.6) (P = NR)
| | | G1: 7.7 (4.6) | | | | | (P = NR) | G2: 16.5 (18.7) (P = NR)
| | | G2: 5.9 (3.9) | | | | | | 9 mos:
| | | (P = NR) | | | | | | G1: 20.3 (27.0) (P = NR)
| | | Civil Status: | | | | | | G2: 20.5 (23.9) (P = NR)
| | | Single: | | | | | | Diff over time (P = NS)
| | | G1: 24 (71%) | | | | | | Diff between groups (P = NS)
| | | G2: 24 (71%) | | | | | | Diff between groups in change over time (P = NS)
| | | (P = NR) | | | | | EDE-Restraint, mean (SD): | EDE-Restraint, mean (SD):
| | | Married/cohabitating: | | | | | G1: 3.3 (1.0) | 6 mos:
| | | G1: 5 (15%) | | | | | G2: 3.3 (0.8) | G1: 2.8 (1.3) (P = NR)
| | | G2: 9 (26%) | | | | | (P = NR) | G2: 2.6 (1.4) (P = NR)
| | | (P = NR) | | | | | | 9 mos:
| | | Other: | | | | | | G1: 2.4 (1.4) (P = NR)
| | | G1: 5 (15%) | | | | | | G2: 2.8 (1.1) (P = NR)
| | | G2: 1 (3%) | | | | | | Diff over time (P = NS)
| | | (P = NR) | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE Eating Concern, mean (SD): | EDE Eating Concern, mean (SD):
| | | | | | | | G1: 2.4 (1.2) | 6 mos:
| | | | | | | | G2: 2.5 (1.0) | G1: 2.0 (1.3) (P = NR)
| | | | | | | | (P = NR) | G2: 2.1 (1.3) (P = NR)
| | | | | | | | | 9 mos:
| | | | | | | | | G1: 1.8 (1.3) (P = NR)
| | | | | | | | | G2: 1.9 (1.2) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE Wt concern, mean (SD): | EDE Wt concern, mean (SD):
| | | | | | | | G1: 3.1 (1.3) | 6 mos:
| | | | | | | | G2: 3.4 (1.3) | G1: 2.6 (1.4) (P = NR)
| | | | | | | | (P = NR) | G2: 3.0 (1.2) (P = NR)
| | | | | | | | | 9 mos:
| | | | | | | | | G1: 2.5 (1.5) (P = NR)
| | | | | | | | | G2: 2.9 (1.3) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE Shape concern, mean (SD): | EDE Shape concern, mean (SD):
| | | | | | | | G1: 3.4 (1.2) | 6 mos:
| | | | | | | | G2: 3.9 (1.1) | G1: 2.9 (1.3) (P = NR)
| | | | | | | | (P = NR) | G2: 3.3 (1.2) (P = NR)
| | | | | | | | | 9 mos:
| | | | | | | | | G1: 2.9 (1.3) (P = NR)
| | | | | | | | | G2: 3.0 (1.3) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE Global score, mean (SD): | EDE Global score, mean (SD):
| | | | | | | | G1: 3.0 (1.0) | 6 mos:
| | | | | | | | G2: 3.3 (0.8) | G1: 2.6 (1.2) (P = NR)
| | | | | | | | (P = NR) | G2: 2.8 (1.0) (P = NR)
| | | | | | | | | 9 mos:
| | | | | | | | | G1: 2.4 (1.2) (P = NR)
| | | | | | | | | G2: 2.6 (1.0) (P = NR)
| | | | | | | | | Diff over time (P = 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | G1: 16 wkly CBT sessions. G2: 16 wks but only 8 fortnightly tx sessions). First 4 sessions - chapters 1–6of CBT manual; remaining sessions: chose most relevant chapters to focus on. | ANCOVA: if additional tx influenced outcome; T-tests: diffs between tx and for demographics with most conservative F values (lower bound epsilon) and followed by approximate test for nonsign. | Score: | Values presented for the Completer sample (N = 48) first, followed by the Randomized sample (N = 62) (when available) | Both txs led to improvements on all measures through FU (text) | | | BMI, kg/m^2^, mean (SD): | BMI at FU, kg/m^2^, mean (SD):
Thiels et al., 1998 | To evaluate the effectiveness of guided self-change for BN. | G1: CBT (16 wkly sessions) | G1: 28.7 (9.1) | DSM III-R criteria BN or if prolonged dx of BN but recently improved and thus not currently meeting criteria. | Both groups: 50 – 50 minutes sessions. | Results: Yates-corrected chi-square test: categorical data; confidence interval analysis: abstinence rates. | Fair | | | | | Total sample: 21.95 (3.56) | Total sample: 21.93 (3.11)
Setting: | | G2: Guided Self-change (8 fortnightly guided sessions) | G2: 27.5 (6.9) | Exclusion: | | | Intent to treat: | | | | | G1: 21.31 (3.11) | G1: NR
Outpatient, Germany | | Enrollment: | Diff between groups (P = NS) | NR | | | Yes | | | | | G2: 22.57 (3.89) | G2: NR
Enrollment period: | | - Enrolled N = 62; 31 each group (alternating basis); - 13 (21%) dropped out during tx phase:G1: N = 4 (12.9%)G2: N = 9; (29.0%); - 14 (22.6%) of enrolled did not complete FU. No diffs in response to FU by condition. | Sex: | | | | Blinding: | | | | | (P = NS) | Diff between groups in change over time (P = 0.02)
NR | | | NR | | | | NR | EDE Overeating, mean (SD): | EDE Overeating: | BDI, mean (SD): | BDI, mean (SD):
| | | Race/ethnicity: | | | | Adverse events: | G1: 2.95 (0.82) | Mid-tx: | G1: 21.0 (8.3) | Mid-tx:
| | | NR | | | | NR | G2: 3.02 (1.10) | G1: 2.18 (1.07) (P = NR) | G2: 19.5 (8.4) | G1: 12.0 (8.7) (P = NR)
| | | Duration of BN, yrs, mean (SD): | | | | Funding: | (P = NR) | G2: 2.44 (1.22) (P = NR) | (P = NR) | G2: 17.0 (10.2) (P = NR)
| | | G1: 8.5 (9.2) | | | | British council (academic research collaboration project 269), the German academic exchange service, and Bielefeld university of applied sciences | EDE Overeating, mean (SD): | Post-tx: | BDI, mean (SD): | Post-tx:
| | | G2: 6.1 (5.6) | | | | | G1: 2.99 (0.85) | G1: 1.53 (1.55) (P = NR) | G1: 22.4 (9.9) | G1: 9.9 (8.8) (P = NR)
| | | (P = NS) | | | | | G2: 3.00 (1.01) | G2: 2.27 (1.21) (P = NR) | G2: 19.5 (8.6) | G2: 14.8 (11.4) (P = NR)
| | | Age of Onset of BN, yrs, mean (SD): | | | | | (P = NS) | FU: | (P = NS) | FU:
| | | G1: 19.6 (4.7) | | | | | | G1: 1.07 (1.61) (P = NR) | | G1: 11.4 (10.5) (P = NR)
| | | G2: 20.3 (6.3) | | | | | | G2: 1.17 (1.23) (P = NR) | | G2: 10.2 (9.9) (P = NR)
| | | (P = NS) | | | | | | Diff over time (P < 0.001) | | Diff over time (P < 0.001)
| | | Previous BN tx, N (%): | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | G1: 15 (48.4) | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | G2: 12 (40.0) | | | | | EDE Vomiting: | EDE Vomiting: | Self-Concept (self-esteem) Questionnaire, mean (SD): | Self-Concept (self-esteem) Questionnaire, mean (SD):
| | | (P = NS) | | | | | G1: 3.79 (1.71) | Mid-tx: | G1: 95.9 (19.9) | Mid-tx:
| | | Previous AN tx, N (%): | | | | | G2: 3.65 (1.65) | G1: 2.83 (1.93) (P = NR) | G2: 104.3 (22.7) | G1: 111.6 (18.3) (P = NR)
| | | G1: 7 (22.6) | | | | | (P = NR) | G2: 2.83 (1.81) (P = NR) | (P = NR) | G2: 112.0 (30.6) (P = NR)
| | | G2: 3 (10.0) | | | | | EDE Vomiting: | Post-tx: | Self-Concept (self-esteem) Questionnaire, mean (SD): | Post-tx:
| | | (P = NS) | | | | | G1: 3.76 (1.76) | G1: 2.06 (2.30) (P = NR) | G1: 96.3 (26.9) | G1: 119.4 (22.9) (P = NR)
| | | Previous tx for other psychiatric problems, N (%): | | | | | G2: 3.23 (1.86) | G2: 2.57 (1.84) (P = NR) | G2: 103.8 (24.1) | G2: 118.6 (29.2) (P = NR)
| | | G1: 2 (6.5) | | | | | (P = NS) | FU: | (P = NS) | FU:
| | | G2: 10 (33.3) | | | | | | G1: 1.38 (2.00) (P = NR) | | G1: 121.6 (31.3) (P = NR)
| | | (P = 0.02) | | | | | | G2: 1.59 (1.82) (P = NR) | | G2: 139.3 (33.5) (P = NR)
| | | Present co-morbidity, N: | | | | | | Diff over time (P < 0.001) | | Diff over time (P < 0.001)
| | | Affective Disorders: | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | G1: 0 | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | G2: 2 | | | | | EDE Shape Concern, mean (SD): | EDE Shape Concern, mean (SD):
| | | Substance-use Disorders: | | | | | G1: 2.98 (1.47) | Mid-tx:
| | | G1: 0 | | | | | G2: 3.30 (1.82) | G1: 2.94 (1.30) (P = NR)
| | | G2: 0 | | | | | (P = NR) | G2: 2.78 (1.55) (P = NR)
| | | Anxiety/OC Disorders: | | | | | | Post-tx:
| | | G1: 4 | | | | | | G1: 2.37 (1.34) (P = NR)
| | | G2: 2 | | | | | | G2: 2.50 (1.53) (P = NR)
| | | Somatoform Disorders: | | | | | | FU:
| | | G1: 2 | | | | | | G1: 2.32 (1.68) (P = NR)
| | | G2: 2 | | | | | | G2: 1.68 (1.43) (P = NR)
| | | AN: | | | | | | Diff over time (P < 0.001)
| | | G1: 0 | | | | | | Diff between groups (P = NS)
| | | G2: 0 | | | | | | Diff between groups in change over time (P = NS)
| | | All (P = NS) | | | | | EDE Wt Concern, mean (SD): | EDE Wt Concern, mean (SD):
| | | | | | | | G1: 3.53 (1.40) | Mid-tx:
| | | | | | | | G2: 3.20 (1.42) | G1: 2.83 (1.39) (P = NR)
| | | | | | | | (P = NR) | G2: 3.05 (1.75) (P = NR)
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 2.21 (1.63) (P = NR)
| | | | | | | | | G2: 2.42 (1.95) (P = NR)
| | | | | | | | | FU:
| | | | | | | | | G1: 1.92 (1.57) (P = NR)
| | | | | | | | | G2: 1.83 (1.57) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE Dietary restraint, mean (SD): | EDE Dietary restraint, mean (SD):
| | | | | | | | G1: 3.79 (1.71) | Mid-tx:
| | | | | | | | G2: 3.65 (1.65) | G1: 2.42 (1.37) (P = NR)
| | | | | | | | (P = NR) | G2: 2.63 (1.44) (P = NR)
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 1.83 (1.45) (P = NR)
| | | | | | | | | G2: 2.34 (1.46) (P = NR)
| | | | | | | | | FU:
| | | | | | | | | G1: 1.56 (1.80) (P = NR)
| | | | | | | | | G2: 1.46 (1.57) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE Severity, mean (SD): | EDE Severity, mean (SD):
| | | | | | | | G1: 4.17 (0.65) | Mid-tx:
| | | | | | | | G2: 4.05 (0.58) | G1: 3.04 (1.02) (P = NR)
| | | | | | | | (P = NR) | G2: 3.41 (1.10) (P = NR)
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 2.43 (1.44) (P = NR)
| | | | | | | | | G2: 3.18 (1.22) (P = NR)
| | | | | | | | | FU:
| | | | | | | | | G1: 2.26 (1.36) (P = NR)
| | | | | | | | | G2: 2.32 (1.49) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | BITE score, mean (SD): | BITE score, mean (SD):
| | | | | | | | G1: 30.1 (5.0) | Mid-tx:
| | | | | | | | G2: 33.8 (9.4) | G1: 23.8 (9.4) (P = NR)
| | | | | | | | (P = NR) | G2: 28.1 (11.0) (P = NR)
| | | | | | | | BITE score, mean (SD): | Post-tx:
| | | | | | | | G1: 32.0 (5.6) | G1: 17.0 (13.1) (P = NR)
| | | | | | | | G2: 34.1 (8.5) | G2: 27.0 (12.3) (P = NR)
| | | | | | | | (P = NS) | FU:
| | | | | | | | | G1: 15.4 (14.2) (P = NR)
| | | | | | | | | G2: 18.2 (12.5) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = 0.05)
| | | | | | | | | G2 better than G1
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Eating Disorders Awareness Test, mean (SD): | Eating Disorders Awareness Test, mean (SD):
| | | | | | | | G1: 21.5 (6.9) | Mid-tx:
| | | | | | | | G2: 22.5 (7.8) | G1: 26.3 (6.7) (P = NR)
| | | | | | | | (P = NR) | G2: 33.0 (9.7) (P = NR)
| | | | | | | | Eating Disorders Awareness Test, mean (SD): | Post-tx:
| | | | | | | | G1: 22.8 (7.6) | G1: 29.6 (8.3) (P = NR)
| | | | | | | | G2: 23.1 (7.9) | G2: 34.3 (10.3) (P = NR)
| | | | | | | | (P = NS) | FU:
| | | | | | | | | G1: 32.5 (8.0) (P = NR)
| | | | | | | | | G2: 35.5 (9.4) (P = NR)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Abstinence rates, N (%) (95% CI):
| | | | | | | | | Stopped binge eating in previous wk:
| | | | | | | | | Mid-tx (N = 31):
| | | | | | | | | G1: 10 (32.3%) (16.7 – 51.4)
| | | | | | | | | G2: 6 (19.4%) (7.5 – 48.0)
| | | | | | | | | Post-tx (N = 31):
| | | | | | | | | G1: 19 (61.3%) (42.2 – 78.1) (P = NR)
| | | | | | | | | G2: 5 (16.1%) (5.5 – 33.7) (P = NR)
| | | | | | | | | FU (G1, N = 24; G2 N = 23):
| | | | | | | | | G1: 17 (70.8%) (48.9 – 87.4) (P = NR)
| | | | | | | | | G2: 16 (69.6%) (47.1 – 86.8) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Stopped vomiting in previous wk:
| | | | | | | | | Mid-tx (N = 31):
| | | | | | | | | G1: 9 (29.0%) (14.2 – 48.0)
| | | | | | | | | G2: 9 (29.0%) (14.2 – 48.0)
| | | | | | | | | Post-tx (N = 31):
| | | | | | | | | G1: 17 (54.8%) (36.0 – 72.7) (P = NR)
| | | | | | | | | G2: 8 (25.8%) (11.9 – 44.6) (P = NR)
| | | | | | | | | FU (G1, N = 24; G2, N = 23):
| | | | | | | | | G1: 17 (70.8%) (48.9 – 87.4) (P = NR)
| | | | | | | | | G2: 14 (60.9%) (38.5 – 80.3) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Stopped binge eating and vomiting combined:
| | | | | | | | | Mid-tx (N = 31):
| | | | | | | | | G1: 8 (25.8%) (11.9 – 44.6)
| | | | | | | | | G2: 5 (16.1%) (5.5 – 33.7)
| | | | | | | | | Post tx (N = 31):
| | | | | | | | | G1: 17 (54.8%) (36.0 – 72.7) (P = NR)
| | | | | | | | | G2: 4 (12.9%) (3.6 – 29.8) (P = NR)
| | | | | | | | | FU (G1, N = 24; G2, N = 23):
| | | | | | | | | G1: 17 (70.8%) (48.9 – 87.4) (P = NR)
| | | | | | | | | G2: 14 (60.9%) (38.5 – 80.3) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | G1 was allocated the manual, asked to work at their own pace and were told that the manual contained all the information needed for them to overcome their BN. They were asked to keep a therapeutic diary (this was used as part of the assessment at 8 wks). After 8 wks, patients who remained symptomatic were offered up to 8 sessions of CBT. Those who no longer met criteria for BN or atypical BN were invited to come for FU at 16 wks. | T tests were used to test for group diffs at baseline. Chi-square analyses were done for categorical data. Wilcoxon tests were used to assess within group changes for bulimic symptom scores, which were not normally distributed. | Score: | | End of tx: | NR | NR | NR | NR
Treasure et al., 1996 | Examine if sequential program (self-help manual for 8 wks followed by 8 sessions of CBT for patients who remained symptomatic) is different from standard CBT (16 wks administered consecutively or following an 8-wk waiting period). | G1: Self-help manual/sequential tx (N = 55) | G1: 25.6 (5.5) | ICD-10 dx of BN or atypical BN | G2 was subdivided into two grps. Half of them were offered immediate CBT for 16 wks and the other half were offered tx after a waiting period of 8 wks after which they received 16 wks of CBT (this group was a waiting list control in Treasure, 1994). The two subgroups were combined at the end of their txs for comparisons with G1. | | Poor | Bulimia rating scale symptom score, median: | Bulimia rating scale symptom score, median:
Companion article: | | G2: standard CBT (N = 55)* | G2: 25.9 (6.3) | Exclusion: | Patients were considered fully recovered if they were not bingeing, vomiting or using any other wt control behaviors or if information was not available, their BITE symptom score was < or equal to 11 and their BITE severity score was 0. | | Intent to treat: | G1: 6 | G1: 2 (P = 0.00)
Turnbull et al., 1997 | | Enrollment: | (P = NS) | Individuals were excluded for severe comorbidity (diabetes, high risk of suicide or alcohol dependence) or pregnancy. | | | Yes | G2: 6 | G2: 2 (P = 0.00)
Setting: | | - 125 consecutive referrals with a dx of BN or atypical BN were screened; - 7 were excluded; 8 declined; - 110 patients randomized; - From G1, 41 attended assessment at 8 wks, 46 at 16 wks and 30 at 18 mos; - In G2, subgroup 1 (immediate tx) consisted of 27 individuals and subgroup 2 (delayed tx) had 28 individuals.; - Of the 55 in G2, 40 were reassessed at 16 wks (end of tx) and 34 at 18 mos.; - 86 completed tx; - 18 mos after tx (14–26 mos), all patients were contacted and sent a questionnaire. 64 responded. FU took place in person or by phone. | Age at onset, yrs, mean (SD): | | | | Blinding: | (P = NR) | Diff between groups (P = NR)
Tertiary referral center in UK | | * Half of the individuals in the CBT group (delayed tx) served as waiting list control participants in another study – Treasure et al., 1994). | G1: 17.5 (4.8) | | | | NA | | Diff between groups in change over time (P = NR)
Enrollment period: NR | | | G2: 17.0 (4.4) | | | | Adverse events: | | Total remission rate/“fully recovered” (no bingeing, vomiting or using any other wt control mechanism):
| | | (P = NS) | | | | NR | | G1: 30%
| | | Illness Duration, yrs, mean (SD): | | | | Funding: | | G2: 30%
| | | G1: 8.0 (5.0) | | | | Mental Health Foundation and Medical Research Council | | Diff between groups (P = NS)
| | | G2: 9.1 (6.5) | | | | | | Diff between groups in change over time (P = NR)
| | | (P = NS) | | | | | | 18 mo FU:
| | | Sex: | | | | | | Bulimia rating scale symptom score, median:
| | | NR | | | | | | G1: 1.5 (P = NS)
| | | Race/ethnicity: | | | | | | G2: 1 (P = NS)
| | | NR | | | | | | Diff between groups (P = NR)
| | | BMI, kg/m ^ 2 ^ , mean (SD): | | | | | | Diff between groups in change over time (P = NR)
| | | G1: 23.7 (5.4) | | | | | | Total remission rate/“fully recovered”:
| | | G2: 24.4 (6.4) | | | | | | G1: 40%
| | | (P = NS) | | | | | | G2: 41%
| | | Total symptom score: | | | | | | Diff between groups (P = NS)
| | | G1: 6 | | | | | | Diff between groups in change over time (P = NR)
| | | G2: 6 | | | | | | Additional tx sought:
| | | (P = NS) | | | | | | G1: 38%
| | | Hx of AN: | | | | | | G2: 17%
| | | G1: 29% | | | | | | Diff between groups (P = NS)
| | | G2: 28% | | | | | | Diff between groups in change over time (P = NR)
| | | (P = NS)
| | | Previous tx:
| | | G1: 44%
| | | G2: 55%
| | | (P = NS)
| | | Current depression:
| | | G1: 23%
| | | G2: 35%
| | | (P = NS)
| | | Current amenorrhea:
| | | G1: 12%
| | | G2: 10%
| | | (P = NS)
| | | Social class (Professional class):
| | | G1: 53%
| | | G2: 56%
| | | (P = NS)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | G1 was allocated the manual, asked to work at their own pace and were told that the manual contained all the information needed for them to overcome their BN. They were asked to keep a therapeutic diary (this was used as part of the assessment at 8 wks). After 8 wks, patients who remained symptomatic were offered up to 8 sessions of CBT. Those who no longer met criteria for BN or atypical BN were invited to come for FU at 16 wks. | Stepwise linear regressions to predict outcome at end of tx and at 18 mo FU. As there was no diff between the two groups, some of the data was pooled to look at predictors. | Score: | | Global Symptoms (sum of binge frequency, vomiting, laxative and/or diuretic abuse, intense exercising): | NR | NR | NR | NR
Turnbull et al., 1997 | Examined pre tx predictors of outcome for two tx's for BN. Outcome (i.e., severity of eating disorder psychopathology) was defined as a sum of binge frequency, vomiting, abuse of laxatives or diuretics, and intense exercising. | G1: Self-help manual/sequential tx (N = 55) | G1: 25.6 (5.5) | ICD-10 dx of BN or atypical BN | G2 was subdivided into two grps. Half of them were offered immediate CBT for 16 wks and the other half were offered tx after a waiting period of 8 wks after which they received 16 wks of CBT (this group was a waiting list control in Treasure, 1994). The two subgroups were combined at the end of their txs for comparisons with G1. | | Poor | | End of tx:
Companion article: | | G2: standard CBT (N = 55) | G2: 25.9 (6.3) | Exclusion: | Patients were considered fully recovered if they were not bingeing, vomiting or using any other wt control behaviors or if information was not available, their BITE symptom score was < or equal to 11 and their BITE severity score was 0. | | Intent to treat: | | Duration of illness as predictor:
Treasure et al., 1996 | | Enrollment: | (P = NS) | Individuals were excluded for severe comorbidity (diabetes, high risk of suicide or alcohol dependence) or pregnancy. | | | Yes | | G1: NR (P = NS)
Setting: | | - 125 consecutive referrals with a dx of BN or atypical BN were screened; - 7 were excluded; 8 declined; - 110 patients randomized; - From G1, 41 attended assessment at 8 wks, 46 at 16 wks and 30 at 18 mos; - In G2, subgroup 1 (immediate tx) consisted of 27 individuals and subgroup 2 (delayed tx) had 28 individuals.; - Of the 55 in G2, 40 were reassessed at 16 wks (end of tx) and 34 at 18 mos.; - 86 completed tx; - 18 mos after tx (14–26 mos), all patients were contacted and sent a questionnaire. 64 responded. FU took place in person or by phone. | Age at onset, yrs, mean (SD): | | | | Blinding: | | G2: NR (P < 0.02)
Tertiary referral center in UK | | | G1: 17.5 (4.8) | | | | NA | | Diff between groups (P = NR)
Enrollment period: | | | G2: 17.0 (4.4) | | | | Adverse events: | | Diff between groups in change over time (P = NR)
NR | | | (P = NS) | | | | NR | | Binge frequency as predictor:
| | | Sex: | | | | Funding: | | G1: NR (P < 0.05)
| | | NR | | | | Mental Health Foundation and Medical Research Council | | G2: NR (P = NS)
| | | Race/ethnicity: | | | | | | Diff between groups (P = NR)
| | | NR | | | | | | Diff between groups in change over time (P = NR)
| | | BMI, kg/m^2^, mean (SD): | | | | | | 18 mo FU:
| | | G1: 23.7 (5.4) | | | | | | Duration of illness as predictor:
| | | G2: 24.4 (6.4) | | | | | | G1: NR (P = NS)
| | | (P = NS) | | | | | | G2: NR (P = NS)
| | | Total symptom score: | | | | | | Diff between groups (P = NR)
| | | G1: 6 | | | | | | Diff between groups in change over time (P = NR)
| | | G2: 6 | | | | | | Binge frequency as predictor:
| | | (P = NS) | | | | | | G1: NR (P < 0.05)
| | | Hx of AN: | | | | | | G2: NR (P = NS)
| | | G1: 29% | | | | | | Diff between groups (P = NR)
| | | G2: 28% | | | | | | Diff between groups in change over time (P = NR)
| | | (P = NS)
| | | Previous tx:
| | | G1: 44%
| | | G2: 55%
| | | (P = NS)
| | | Current depression:
| | | G1: 23%
| | | G2: 35%
| | | (P = NS)
| | | Current amenorrhea:
| | | G1: 12%
| | | G2: 10%
| | | (P = NS)
| | | Social class (Professional class):
| | | G1: 53%
| | | G2: 56%
| | | (P = NS)

Evidence Table 9. Other trials for bulimia nervosa

| | | | | | | | Eating Related Measures | | Psychological/Psychiatric Measures | | Biomarkers
Study Description | Objective | Design | Patient Characteristics | Inclusion/Exclusion Criteria | Treatment | Statistical Methods | Quality | Baseline | Outcomes | Baseline | Outcomes | Baseline | Outcomes
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Parallel-design, 8 wk study, taking place during winter mos (Nov-Dec; Jan-March); 3 wk baseline data collection followed by 3 wk tx period, and 2 wks FU; all subjects received Apollo light boxes to deliver either 10,000 lux white light (G1) or 50 lux red light (G2) arriving at the retina; all used lights ½ hr/day at home between 6 and 9pm while watching television; daily phone contact with about compliance with participants, who avoided outdoor light before 8am or used sunglasses. | MANOVA across time points was used to assess light tx by time interaction; Pearson r correlations between the change in various outcome measures were computed in groups; ANOVA was used to assess diff between group s in change over time. | Score: | Binge Frequency, wkly, mean (SD): | Binge Frequency, wkly, mean (SD): | BDI, mean (SD): | BDI, mean (SD):
Braun et al., 1999 | During a 3-wk winter tx period, to assess the efficacy of winter bright light therapy versus dim red light (Placebo) therapy on binge and purge frequency and depressive sx in women with BN. | G1: Active light (N = 16) | G1: 30.50 (7.3) | Met DSM IV criteria for BN; age 18 to 50; premenopausal | For 8 wks, all completed daily food diaries, including B/P behaviors, urge to binge, meals and snacks, carbohydrate cravings, menstrual ad sleep logs, and BDIs. | | Fair | G1: 6.7 (3.1) | Post-tx: | G1: 16.9 (9.4) | Post-tx:
Setting: | | G2: Dim light/Placebo (N = 18) | G2: 30.50 (8.6) | Exclusion: | At baseline, tx-end, and 2-wk FU, wt, BDI, HAM-D, Seasonal Patterns Assessment Questionnaire (SPAQ) and YBC-EDS were assessed. | | Intent to treat: | G2: 4.9 (2.9) | G1: 4.3 (3.9) (P = NR) | G2: 13.1 (9.1) | G1: 13.0 (7.5) (P = NR)
Outpatient, New York, USA | | Enrollment: | (P = NS) | Current drug or alcohol abuse or dependence, bipolar disorder, schizophrenia, ophthalmologic disease, serious medical conditions, or current wt less that 90% IBW (Metropolitan Table); current anorexia; involvement in psychotherapy regimen or taking psychiatric meds for less than 3 mos prior to study; change in therapeutic tx or meds immediately preceding or during study | | | NR | (P = NS) | G2: 3.9 (3.3) (P = NR) | (P = NS) | G2: 10.8 (9.1) (P = NR)
Enrollment period: NR | | - Recruited via therapist or newspaper ads; - Subjects matched for age, degree of seasonality (measured by Seasonal Patterns Assessment Questionnaire), and concurrent depression (DSM IV); - Total screened = N; - 34 enrolled | Sex: | | | | Blinding: | | 2 wk FU: | | 2 wk FU:
| | | Female: 100% | | | | Double | | G1: 4.1 (4.5) (P = NR) | | G1: 11.9 (8.7) (P = NR)
| | | Race/ethnicity: | | | | Adverse events: | | G2: 3.6 (3.3) (P = NR) | | G2: 10.5 (8.7) (P = NR)
| | | NR | | | | No subjects withdrew due to side effects; 5 were removed from G1 due to med change, vacation in sun, noncompliance, and failure to meet binge frequency at baseline; 5 G2 were removed due to failure to meet BN criteria. | | Diff over time (P = NR) | | Diff over time (P = 0.003)
| | | Current Major Depression: | | | | Funding: | | Diff between groups (P = NR) | | Diff between groups (P = NS)
| | | G1: 25% (N = 4) | | | | NIMH and fund established by the NY Community Trust by Dewitt-Wallace | | Diff between groups in change over time (P = 0.017) | | Diff between groups in change over time (P = NS)
| | | G2: 22.2% (N = 4) | | | | | | G1 better than G2 in change from baseline to post-tx
| | | Lifetime Major Depression: | | | | | Purge Frequency, wkly, mean (SD): | Purge Frequency, wkly, mean (SD): | HAM-D, mean (SD): | HAM-D, mean (SD):
| | | G1: 75% (12) | | | | | G1: 7.7 (4.8) | Post-tx: | G1: 7.9 (6.7) | Post-tx:
| | | G2: 72.2% (13) | | | | | G2: 6.3 (5.9) | G1: 5.2 (4.5) (P = NR) | G2: 9.7 (7.6) | G1: 3.7 (3.7) (P = NR)
| | | No patients met criteria for major depression with a seasonal pattern. | | | | | (P = NS) | G2: 4.3 (4.0) (P = NR) | (P = NS) | G2: 5.5 (4.1) (P = NR)
| | | | | | | | | 2 wk FU: | | 2 wk FU:
| | | | | | | | | G1: 4.5 (6.2) (P = NR) | | G1: 4.4 (4.4) (P = NR)
| | | | | | | | | G2: 4.2 (4.2) (P = NR) | | G2: 4.7 (6.4) (P = NR)
| | | | | | | | | Diff over time (P = NR) | | Diff over time (P = 0.005)
| | | | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | | Meal Frequency, wkly, mean (SD): | Meal Frequency, wkly, mean (SD): | HAM-D-SAD items, mean (SD): | HAM-D-SAD, mean (SD):
| | | | | | | | G1: 14.5 (5.0) | Post-tx: | G1: 5.7 (3.6) | Post-tx:
| | | | | | | | G2: 16.3 (3.8) | G1: 16.4 (4.0) (P = NR) | G2: 5.5 (4.1) | G1: 2.3 (2.3) (P = NR)
| | | | | | | | (P = NS) | G2: 16.8 (3.4) (P = NR) | (P = NS) | G2: 2.4 (2.2) (P = NR)
| | | | | | | | | 2 wk FU: | | 2 wk FU:
| | | | | | | | | G1: 17.4 (3.5) (P = NR) | | G1: 5.6 (4.5) (P = NR)
| | | | | | | | | G2: 16.5 (3.7) (P = NR) | | G2: 4.0 (5.5) (P = NR)
| | | | | | | | | Diff over time (P = NR) | | Diff over time (P = 0.014)
| | | | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | | YBC-EDS, total, mean (SD): | YBC-EDS, total, mean (SD):
| | | | | | | | G1: 15.1 (4.5) | G1: 11.4 (6.0) (P = NR)
| | | | | | | | G2: 16.4 (5.1) | G2: 13.4 (5.9) (P = NR)
| | | | | | | | (P = NS) | 2 wk FU:
| | | | | | | | | G1: 10.4 (7.4) (P = NR)
| | | | | | | | | G2: 11.8 (7.4) (P = NR)
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Seasonal Patterns Assessment Questionnaire (SPAQ): | Seasonal Patterns Assessment Questionnaire (SPAQ):
| | | | | | | | G1: 43.8% (16) met full criteria for SAD, 18.8% (3) met sub-threshold criteria | G1: NR
| | | | | | | | G2: 44.4% (18) met SAD criteria, 16.7% (3) met sub-threshold. | G2: NR
| | | | | | | | SPAQ GSS, mean (SD): | (P = NR)
| | | | | | | | G1: 11.1 (5.2) | Correlation between change in HAM-D-SAD scores and change in carbohydrate craving
| | | | | | | | G2: 11.0 (5.3) | G1: (r = 0.66) (P = 0.38)
| | | | | | | | (P = NS) | G2: (r = -.41) (P = 0.24)
| | | | | | | | SPAQ Sleep, mean (SD): | Correlation between change in HAM-D-SAD scores and change in binge frequency
| | | | | | | | G1: 1.5 (1.2) | G1: (r = 0.44) (P = 0.20)
| | | | | | | | G2: 1.3 (1.1) | G2: (r = -.75) (P = 0.012)
| | | | | | | | (P = NS)
| | | | | | | | SPAQ -Wt, mean (SD):
| | | | | | | | G1: 1.8 (1.1)
| | | | | | | | G2: 1.3 (1.1)
| | | | | | | | (P = NS)
| | | | | | | | SPAQ Appetite, mean (SD):
| | | | | | | | G1: 1.7 (1.0)
| | | | | | | | G2: 1.6 (1.2)
| | | | | | | | (P = NS)
| | | | | | | | SPAQ Energy, mean (SD):
| | | | | | | | G1: 2.2 (1.1)
| | | | | | | | G2: 2.3 (1.2)
| | | | | | | | (P = NS)
| | | | | | | | From baseline to Tx-end, SPAQ global scores were not correlated with change in binge frequency.
Author, yr: | Research objective: | Groups enrolled: | Age, yrs, mean (SD): | Inclusion: | Pre-tx assessment | 2 (group) × 2 (time) repeated measures ANOVA; regression analysis of psych variables on eating behaviors; correlations between psych variables; Chi Square for abstinence rates. | Score: | Binge frequency/wk, mean (SD): | Binge Frequency/wk, mean (SD):
Esplen et al., 1998 | To test the efficacy of a guided image therapy to enhance self-comfort in individuals with BN vs. a control tx of eating behavior journaling therapies | G1: guided imagery (N = 28) | G1: 27.2 (6.3) | DSM III-R criteria for BN | Randomization | Active dose = 4 wks of therapy, so “completer” was ≥ 4 session attendance | Fair | G1: 5.6 (3.5) | G1: 1.7 (1.7) (P = NR)
Setting: | | G2: control (N = 30) | G2: 26.1 (5.8) | CBW > 85% of avg for sex, age, and height < 15 yr illness duration no current psych tx no risk factors for inpatient tx | G1: 6 wkly sessions of manual-based guided imagery exercises on relaxation and self-exploration; take-home tape provided; journaling | | Intent to treat: | G2: 4.9 (2.6) | G2: 5.2 (2.6) (P = NR)
Outpatient; Toronto, Canada | | Enrollment: | (P = NS) | Exclusion: | G2: 6 wkly sessions of manual-based explorations of eating pattern journals; comments on observed patterns but no guidelines | | No | (P = NS) | Diff over time (P < 0.001)
Enrollment period: 20 mos | | Potential subjects referred by consultation service (N = 51) or in response to advertisements (N = 7) Informed consent Pre-tx psychometric assessment Randomization 6 wks of tx Post-tx psychometric assessment | Sex: | Current psych tx or Indications for inpatient tx | Post-assessment | | Blinding: | | Diff between groups (P = 0.05)
| | Drop-outs: | 96.5% female | | | | No | | Diff between groups in change over time
| | G1: N = 4 | Race/ethnicity: | | | | Adverse events: | | (P < 0.001)
| | G2: N = 4 | NR | | | | Not reported | | G1 better than G2
| | Completers reported: | BMI, kg/m ^ 2 ^ , mean (SD): | | | | Funding: | | % Reduction in Binge Freq:
| | G1: N = 24 | G1: 21.0 (1.0) | | | | Ontario Mental Health Foundation | | G1: 73.6% (23.9)
| | G2: N = 28 | G2: 21.3 (1.3) | | | | | | G2: - 9.0% (43.4)
| | | (P = NS) | | | | | | (P = NR)
| | | Duration of BN, mos, mean (SD): | | | | | Purge frequency/wk, mean (SD): | Purge Frequency/wk, mean (SD):
| | | G1: 83.0 (55.5) | | | | | G1: 6.3 (5.8) | G1: 1.7 (1.7) (P = NR)
| | | G2: 86.0 (63.9) | | | | | G2: 5.0 (4.6) | G2: 4.8 (4.6) (P = NR)
| | | (P = NS) | | | | | (P = NS) | Diff over time (P < 0.001)
| | | Previous AN, N (%): | | | | | | Diff between groups (P = NS)
| | | Completers: 12 (24%) | | | | | | Diff between groups in change over time (P < 0.001)
| | | Drop-outs: 6 (75%) | | | | | | G1 better than G2
| | | (P = NR) | | | | | | % Reduction in Purge Freq:
| | | | | | | | | G1: 72.5% (26.1)
| | | | | | | | | G2: - 6.2% (32.5)
| | | | | | | | | (P = NR)
| | | | | | | | Abstinence/Remission: | Abstinence, N:
| | | | | | | | G1: NR | G1: 6/24
| | | | | | | | G2: NR | G2: 0/26
| | | | | | | | | (P < 0.001)
| | | | | | | | Eating Disorder Inventory: | Eating Disorder Inventory:
| | | | | | | | Drive for thinness (DT), mean (SD): | Drive for thinness (DT), mean (SD):
| | | | | | | | G1: 14.8 (4.5) | G1: 10.1 (6.4) (P = NR)
| | | | | | | | G2: 14.1 (5.5) | G2: 15.5 (5.4) (P = NR)
| | | | | | | | (P = NR) | Diff over time (P = 0.015)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P < 0.001)
| | | | | | | | | G1 better than G2
| | | | | | | | | % Making Sig DT improvement:
| | | | | | | | | G1: 50.0
| | | | | | | | | G2: 3.8
| | | | | | | | | Diff between groups (P < 0.0002)
| | | | | | | | Bulimia (B), mean (SD): | Bulimia (B), mean (SD):
| | | | | | | | G1: 9.4 (5.0) | G1: 4.7 (5.1) (P = NR)
| | | | | | | | G2: 11.5 (5.5) | G2: 11.9 (5.7) (P = NR)
| | | | | | | | (P = NR) | Diff over time (P = 0.002)
| | | | | | | | | Diff between groups (P = 0.001)
| | | | | | | | | Diff between groups in change over time (P < 0.001)
| | | | | | | | | G1 better than G2
| | | | | | | | | % Making Sig B improvement:
| | | | | | | | | G1: 37.5
| | | | | | | | | G2: 3.8
| | | | | | | | | Diff between groups (P < 0.004)
| | | | | | | | Body Dissatisfaction (BD), mean (SD): | Body Dissatisfaction (BD), mean (SD)
| | | | | | | | G1: 16.1 (8.8) | G1: 12.5 (8.7) (P = NR)
| | | | | | | | G2: 18.9 (7.9) | G2: 18.7 (7.7) (P = NR)
| | | | | | | | (P = NR) | Diff over time (P = 0.028)
| | | | | | | | | Diff between groups (P = 0.05)
| | | | | | | | | Diff between groups in change over time (P < 0.043)
| | | | | | | | | G1 better than G2
| | | | | | | | | % Making Sig BD improvement:
| | | | | | | | | G1: 33.3
| | | | | | | | | G2: 7.7
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | % Making Clinically Sig Improvement on Eating Attitudes Test:
| | | | | | | | | G1: 58%
| | | | | | | | | G2: < 10%
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | Total score (P < 0.001)
| | | | | | | | | Bulimia subscale (P < 0.001)
| | | | | | | | | Dieting subscale (P < 0.001)
| | | | | | | | | G1 better than G2
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Within the crisis intervention model, participants could request additional tx if they became symptomatic or feared they would relapse within the first 17 wks. Emphasis was placed on calling early if problems developed with the intent that participants would be seen quickly for an additional two or three sessions as necessary to reestablish the goals of therapy and to assist in relapse prevention work. Participants were allowed up to 8 sessions during the period of FU. Those in the FU group were contacted for FU assessments only and were not offered further tx. | Cox regression used to test diffs between 2 tx groups in length of time until resumption of bingeing and/or purging. | Score: | | Length of time until resumption of bingeing and purging | NR | NR | NR | NR
Mitchell et al., 2004 | Comparing two outpatient relapse prevention strategies for individuals with BN who have become abstinent from bingeing and purging after CBT tx. | G1: Crisis prevention (N = 30) | G1: 28.8 (8.6) | From the participants in the original study, individuals were included in this study if they had remained abstinent from bingeing and purging in the 28 days prior to the beginning of this tx protocol. | | | Fair | | G1: Data reported in figure only
Companion articles: | | G2: FU (N = 27) | G2: 29.8 (9.4) | Exclusion: | | | Intent to treat: | | G2: Data reported in figure only
Agras, et al., 2000 and Halmi et al., 2002 | | Enrollment: | Sex: | Individuals from the original study who were bingeing or purging at the end of CBT tx. | | | NR | | Diff between groups (P = NR)
Setting: | | - In the original study, 194 participants were screened by phone, interviewed and recruited to receive CBT.; - 6 participants withdrew and 48 dropped out during the CBT tx.; - After 140 individuals completed CBT, between wks 16 and 17, patients were reassessed relative to their remission status.; - 57 individuals achieved abstinence (defined as abstinence from bingeing and purging in the last 28 days) and were randomized to FU only or crisis intervention.; - In this study, participants were reassessed at 17, 43 and 70 wks after tx.; - 48 individuals completed the 17-wk FU assessment after end of tx, 41 completed the assessments at 43 wks and 34 completed the 70 wk FU. | NR | | | | Blinding: | | Diffs between groups in time to resumption (P = NS)
Outpatient, Cornell University, Rutgers University and University of Minnesota, USA | | | Race/ethnicity: | | | | NA
Enrollment period: NR | | | NR | | | | Adverse events:
| | | Hx of anorexia: | | | | 37% of the participants resumed bingeing or purging by the end of the 17-wk FU period. An additional 16% of the participants resumed bulimic behavior within the yr after the FU tx. Of the individuals who resumed bulimic behavior, only 4 met criteria for BN according to DSM III-R.
| | | G1: 7% | | | | Funding:
| | | G2: 22% | | | | McKnight Foundation and Minnesota Obesity Center
| | | Hx of depression:
| | | G1: 53%
| | | G2: 48%
| | | Personality disorder:
| | | G1: 27%
| | | G2: 33%
| | | Hx of substance abuse:
| | | G1: 10%
| | | G2: 22%
| | | Duration of bingeing (SD):
| | | G1: 10.6 (8.1)
| | | G2: 12.1 (8.9)
| | | (P = NS)
| | | Duration of purging (SD):
| | | G1: 10.27 (7.4)
| | | G2: 12.0 (9.0)
| | | (P = NS)
| | | Pre-CBT objective binges:
| | | G1: 18
| | | G2: 19
| | | (P = NS)
| | | Pre-CBT purges:
| | | G1: 27
| | | G2: 28
| | | (P = NS)

Evidence Table 10. Medication trials for binge eating disorder

| | | | | | | | Eating Related Measures | | Psychological/Psychiatric Measures | | Biomarkers
Study Description | Objective | Design | Patient Characteristics | Inclusion/Exclusion Criteria | Treatment | Statistical Methods | Quality | Baseline | Outcomes | Baseline | Outcomes | Baseline | Outcomes
Author, yr: | Research objective: | Groups: | Age yrs, mean (SD): | Inclusion: | After completing entry screening procedures, participants (N = 79) underwent 2-wk, single-blind placebo run-in phase prior to randomization. Subjects who reported binge eating episodes on at least 2 days w/in the last wk and who scored > 17 on the BES were randomized to 12-wks of either 15 mg of sibutramine hydrochloride (N = 30) or placebo (N = 30). Subjects' binge eating frequency, binge eating risk, self-reported depression, and wt were assessed at baseline and at 2, 4, 8, and 12 wks. | Two-tailed, unpaired t tests or X^2^ tests for between group diff in baseline variables; repeated random regression analyses (including time trend analyses) to assess between group changes in primary and secondary variables at baseline, 2, 4, 8, and 12 wks; logistic regression to test between group diff in response (i.e., 50% reduction in binge frequency) and remission (i.e., cessation of binge eating) rates. | Score: | Binge days per wk, mean (SD): | Binge days per wk, mean (SD): | | | Wt, kg, mean (SD): | Wt, kg, mean (SD):
Appolinario et al., 2003 | To assess the efficacy and safety of sibutramine hydrochloride (a serotonin and norepinephrine reuptake inhibitor) in reducing the frequency of binge eating and its effect on wt loss, binge eating risk, and self-reported depression over the course of 12 wks. | G1: sibutramine hydrochloride (N = 30) | G1: 35.2 (9.0) | Ages 18–60; BMI:30–45; DSM IV criteria for BED and BES score ≥ moderate range (i.e., > 17). | | | Good | G1: 4.1 (1.8) | Completion | | | G1: 102.8 (13.2) | Completion
Setting: | | G2: placebo (N = 30) | G2: 36.6 (10.2) | Exclusion: | | | Intent to treat: | G2: 3.9 (1.8) | G1 and G2: Data presented in graph | | | G2: 98.7 (12.9) | G1 and G2: Data presented in graph
Two sites; outpatient; locations: Obesity and Eating Disorders Group, Institute of Psychiatry, Federal University of Rio de Janeiro/Institute of Diabetes and Endocrinology of Rio de Janeiro, Rio de Janeiro, Brazil and the Eating Disorders Program from the Federal University of Sao Paulo, Sao Paulo, Brazil | | Enrollment: | (P = NS) | Pregnant, lactating or not using medically-accepted form of contraception; current or past dx of BN; psychosis; mania; organic dementia; alcohol or other drug abuse; suicide risk; diabetes mellitus; supine diastolic arterial pressure > 110 mm Hg; unstable medical illness or clinically sig abnormal laboratory results; current or previous use of sibutramine or other investigational drugs; concurrent use of antidepressants, antipsychotics, lithium carbonate, cyproheptadine hydrochloride, bromocriptine mesylate, ergotamine tartrate and related drugs, atropine, thyroid hormones, systemic steroids (except menopause hormone therapy), antiobesity agents, drugs that interfere with the GI tract movements such as antidiarrhea and antinausea drugs, anticoagulants, digitalis, anti-Parkinson drugs that interfere with amine activity; any form of psychotherapy within 3 mos of study entry; hx of obesity surgery; smoking cessation within past 3 mos or intent to quit during study period. | | | Yes | (P = NS) | (P = NR) | | | (P = NS) | Diff between groups (P = NS)
Enrollment period: | | - 750 screened by telephone and recruited through media ads; - 233 further in-person evaluation by staff members; - 79 enrolled (19 excluded from the double blind phase for presenting with only 2 binge days during the wk after the placebo run-in phase); - 60 randomized; - 48 completers (G1: 23; G2: 25) (P = NS) | Sex: | | | | Blinding: | | Diff between groups in change over time (P = 0.03): | | | | Diff between groups in change over time (P < 0.001) G1 better than G2
October 1, 2000 through July 31, 2001 | | | % Female | | | | Double | | G1 better than G2 | | | | Wk 2:
| | | G1: 87% | | | | Adverse events, N: | | Wk 2: | | | | G1: 98.7 (11.0)
| | | G2: 90% | | | | Dry mouth: | | G1: 1.7 (1.9) | | | | G2: 99.2 (13.4)
| | | (P = NS) | | | | G1: 22 | | G2: 3.3 (2.2) | | | | Within group change from baseline (P = NR)
| | | Race/ethnicity: | | | | G2: 3 | | Within group change from baseline (P = NR) | | | | (P = NR)
| | | White: | | | | (P < 0.01) | | (P = NR) | | | | Diff between groups in change over time (P = NR)
| | | G1: 73% | | | | Headache: | | Diff between groups in change over time (P = 0.002) | | | | Wk 4:
| | | G2: 87% | | | | G1: 6 | | G1 better than G2 | | | | G1: 96.9 (10.8)
| | | (P = NS) | | | | G2: 14 | | Wk 4: | | | | G2: 99.7 (12.5)
| | | Hx of major depression, N (%): | | | | (P < 0.01) | | G1: 1.7 (1.6) | | | | Within group change from baseline (P = NR)
| | | G1: 11 (37) | | | | Constipation: | | G2: 3.0 (2.1) | | | | (P = NR)
| | | G2: 9 (30) | | | | G1: 7 | | Within group change from baseline (P = NR) | | | | Diff between groups in change over time (P = 0.02) G1 better than G2
| | | (P = NS) | | | | G2: 0 | | (P = NR) | | | | Wk 8:
| | | | | | | (P < 0.001) | | Diff between groups in change over time (P = NR) | | | | G1: 96.0 (11.4)
| | | | | | | All other adverse events (i.e., nausea, insomnia, sudoresis, lumbar pain, depressive mood, flu syndrome, malaise, others) (P = NS). | | Wk 8: | | | | G2: 99.9 (13.3)
| | | | | | | Funding: | | G1: 1.8 (2.2) | | | | Within group change from baseline (P = NR)
| | | | | | | Abbott Laboratories, Sao Paulo, Brazil | | G2: 2.5 (2.1) | | | | (P = NR)
| | | | | | | | | Within group change from baseline (P = NR) | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | (P = NR) | | | | Wk 12:
| | | | | | | | | Diff between groups in change over time (P = NR) | | | | G1: 95.4 (12.3)
| | | | | | | | | Wk 12: | | | | G2: 100.1 (13.6)
| | | | | | | | | G1: 1.4 (2.0) | | | | Within group change from baseline (P = NR)
| | | | | | | | | G2: 2.3 (2.2) | | | | (P = NR)
| | | | | | | | | Within group change from baseline (P = NR) | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.04)
| | | | | | | | | G1 better than G2
| | | | | | | | BES, mean (SD): | BES, mean (SD): | BDI, mean (SD): | BDI, mean (SD):
| | | | | | | | G1: 29.2 (7.2) | Completion | G1: 17.3 (9.7) | Completion
| | | | | | | | G2: 29.1 (5.9) | G1 and G2: Data not presented | G1: 18.6 (9.1) | G1 and G2: Data presented in graph
| | | | | | | | (P = NS) | (P = NR) | (P = NS) | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P < 0.001) | | Diff between groups in change over time (P < 0.001)
| | | | | | | | | G1 better than G2 | | G1 better than G2
| | | | | | | | | Wk 2: | | Wk 2:
| | | | | | | | | G1: 26.8 (9.3) | | G1: 14.6 (7.9)
| | | | | | | | | G2: 27.6 (6.5) | | G2: 19.4 (11.2)
| | | | | | | | | Within group change from baseline (P = NR) | | Within group change from baseline (P = NR)
| | | | | | | | | (P = NR) | | (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | | Wk 4: | | Wk 4:
| | | | | | | | | G1: 23.6 (11.4) | | G1: 13.1 (8.6)
| | | | | | | | | G2: 26.1 (8.8) | | G2: 18.4 (10.4)
| | | | | | | | | Within group change from baseline (P = NR) | | Within group change from baseline (P = NR)
| | | | | | | | | Diff between groups (P = NR) | | (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.04) | | Diff between groups in change over time (P = NR)
| | | | | | | | | G1 better than G2 | | Wk 8:
| | | | | | | | | Wk 8: | | G1: 12.9 (8.5)
| | | | | | | | | G1: 21.0 (12.6) | | G2: 18.3 (10.8)
| | | | | | | | | G2: 26.4 (9.5) | | Within group change from baseline (P = NR)
| | | | | | | | | Within group change from baseline (P = NR) | | (P = NR)
| | | | | | | | | (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Wk 12:
| | | | | | | | | Wk 12: | | G1: 9.9 (7.6)
| | | | | | | | | G1: 19.7 (12.4) | | G2: 17.9 (10.6)
| | | | | | | | | G2: 24.4 (8.9) | | Within group change from baseline (P = NR)
| | | | | | | | | Within group change from baseline (P = NR) | | Diff between groups (P = 0.002)
| | | | | | | | | Diff between groups (P = NR) | | G1 better than G2
| | | | | | | | | Diff between groups in change over time (P = 0.005) G1 better than G2 | | Diff between groups in change over time (P = NR)
| | | | | | | | | Response, N (%) of completers:
| | | | | | | | | G1: 18 (78%)
| | | | | | | | | G2: 13 (52%)
| | | | | | | | | (P = NR)
| | | | | | | | | Diff between groups in change over the 12-wk study (P = 0.005)
| | | | | | | | | G1 better than G2
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | After 1 wk of single-blind placebo admin, subjects randomized to fluoxetine or placebo for 6 wks. Dosage began with 20mg/day for 3 days; As tolerated, dose increased to 40 mg/day for 3 days, then 60 mg/day. After 2 wks, dose could increase to 80 mg/day. At endpoint, mean dose (SD) for G1: 71.3 (11.4); G2: 67.3 (11.5). | PreTx comparisons between groups using Fisher exact test, and 2-sample t tests for continuous variables. | Score: | Binges/wk, mean (SD): | Binges/wk, mean (SE): | | 6 wks: | Baseline: | 6 wks:
Arnold et al., 2002 | To assess the efficacy and safety of fluoxetine in the tx of BED | G1: fluoxetine (N = 30) | G1: 41.9 (9.7) | DSM IV criteria for BED, and ≥ 3 BE episodes wkly for at least 6 mos; age 18–60; wt > 85% IBW. | Subjects seen wkly, and assessed for number of binges since prior visit, CGI-S, meds dose and compliance (capsule count), adverse events, non-study med use, vital signs and wt. | 2 mixed-model repeated-measures analyses were made for each outcome (except response category): a time-trend analyses assessing rate of change between groups, and an endpoint analysis, assessing change between groups from baseline to wk 6. | Good | G1: 6.0 (2.5) | 8-wks: | CGI-S, mean (SD): | CGI-S, mean (SE): | Wt, kg (SD): | Wt, kg (SE):
Setting: | | G2: placebo (N = 30) | G2: 40.8 (9.0) | Exclusion: | HAM-D administered at baseline, wks 2, 4, and 6. | Response categories analyzed using the exact trend test; 2 analyses: for tx completers only, and for all subjects. | Intent to treat: | G2: 6.1 (4.8) | G1: 1.8 (2.9) | G1: 4.2 (0.4) | G1: 2.2 (1.4) | G1: 110.4 (24.1) | G1: 112.5 (25.0)
Outpatient; single center; USA | | Enrollment: | (P = NS) | Pregnant or lactating; concurrent AN; concurrent or recent (within 1 yr) substance abuse or dependence; lifetime hx of psychosis, mania, hypomania, or dementia; hx of any psychiatric disorder that could interfere with diagnostic assessment, tx, or compliance; suicide risk; received psychotherapy or behavioral therapy within 3 mos of entry; clinically unstable medical illness; hx of seizures, lab abnormalities; MAOIs within 4 wks, or psychotropic meds within 2 wks of entry; received investigational meds or depot neuroleptics within 3 mos of entry; previously treated with fluoxetine; experienced < 3 binges in wk before randomization. | | | Yes | (P = NS) | G2: 2.7 (3.8) | G2: 4.3 (0.6) | G2: 3.3 (1.4) | G2: 103.5 (19.0) | G2: 110.3 (18.2)
Enrollment period: | | - 60 enrolled; - 30 assigned to each tx group; - 24 (40%) withdrew over study course (G1: 57%; G2: 23%) | Sex: | | | | Blinding: | | Diff between groups (P = NS) | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR)
February 1998 to June 2000 | | Diff between groups (P = 0.02) | Female | | | | Double | | Diff between groups in log rate of change (P = 0.033) | | Diff between groups in change over time (time trend analysis, P = 0.032; endpoint analysis, P = 0.012) | | Diff between groups in change over time (time trend analysis, P = 0.001; endpoint analysis, P = 0.0001)
| | Of the 24, 10 withdrew, post-baseline | G1: 93% | | | | Adverse events: | | G1 better than G2 | | G1better than G2 | | G1 better than G2
| | | G2: 93% | | | | Most common, reported by G1 (N): | | Percentage decrease in frequency of binges: N (%)
| | | (P = NS) | | | | Sedation (5), dry mouth (11), headache (9), nausea (7), insomnia (7), diarrhea (6), fatigue (6), increased urinary frequency (4), sexual dysfunction (4). | | Intent to treat sample: G1 = 29; G2 = 21
| | | Race/ethnicity: | | | | Across groups, hand and foot swelling, palpitations, and apathy were also reported; no sig diff between groups. | | None ( < 50%): G1: 7 (24); G2: 9 (43)
| | | White: | | | | Funding: | | Moderate (50%–74% decrease): G1: 8 (28); G2: 4 (19)
| | | G1: 90% | | | | Investigator-initiated grant, Eli Lily and Company | | Marked (75%–99% decrease): G1: 1 (3); G2: 3 (14)
| | | G2: 87% | | | | | | Remission (100%): G1: 13 (45) (P = NR) G2: 5 (24) (P = NR)
| | | (P = NS) | | | | | | Diff between groups (P = NS)
| | | AA: | | | | | | Diff between groups in change over time (P = NR)
| | | G1: 10% | | | | | | Percentage decrease in frequency of binges: N (%)
| | | G2: 13% | | | | | | Completers sample: G1 = 23; G2 = 12
| | | (P = NS) | | | | | | None ( < 50%): G1: 4 (17); G2: 4 (33)
| | | Duration of BED yrs, mean (SD): | | | | | | Moderate (50%–74% decrease): G1: 5 (22); G2: 2 (17)
| | | G1: 19.9 (12.5) | | | | | | Marked (75%–99% decrease): G1: 1 (4); G2: 3 (25)
| | | G2: 16.7 (9.5) | | | | | | Remission (100%): G1: 13 (57); G2: 2 (25)
| | | (P = NS) | | | | | | Diff between groups (P = NS)
| | | Current major depressive disorder: | | | | | | Diff between groups in change over time (P = NR)
| | | G1: 27% | | | | | Abstinence rate, N (%): | Abstinence rate N (%): | HAM-D, mean (SD): | HAM-D score (SE): | BMI, kg/m^2^ (SD): | BMI, kg/m^2^ (SE):
| | | G2: 23% | | | | | G1: NR | G1: 13 (45) (P = NR) | G1: 4.8 (4.3) | G1: 2.6 (3.0) | G1: 39.6 (7.0) | G1: 40.0 (7.2)
| | | (P = NS) | | | | | G2: NR | G2: 5 (24) (P = NR) | G2: 4.2 (2.9) | G2: 5.5 (4.1) | G2: 36.7 (6.8) | G2: 39.5 (6.3)
| | | Lifetime (current or past) major depressive disorder (%): | | | | | | (P = NR) | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR)
| | | G1: 67% | | | | | | | | Diff between groups in change over time (time trend analysis, P = NS; endpoint analysis, P = 0.003) | | Diff between groups in change over time (time trend analysis, P = 0.0001; endpoint analysis, P = 0.0001)
| | | G2: 63% | | | | | | | | G1 better than G2 | | G1 better than G2
| | | (P = NS) | | | | | | | | Interaction effects:
| | | | | | | | | | | No evidence for differential effects in subjects with and without current major depressive disorder.
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | One wk lead-in period. During lead-in, patients took one capsule each evening. After that, participants randomly assigned to therapy with fluvoxamine or placebo. Participants seen wkly for a total of nine wks. Dose was 50 mg every evening for a min of three days in the initial part of tx. After day 4, dose could be adjusted on an individual basis (50 mg –300 mg) until end of tx. Adjustments to the number of capsules taken per day were made at discretion of investigator and meds was increased until a patient was asymptomatic or intolerant of higher doses. Binges measured by patient diaries including number of capsules of meds taken. Meds compliance also monitored by counting capsules at wkly visits. The diff between fluvoxamine and placebo groups in number of capsules consumed per day was diff for patients who completed 4 and 9 wks of tx (P < 0.008 and P < 0.007 respectively) | Fisher's exact test for categorical variables and a t test for continuous variables used to compare baseline characteristics. Outcomes analyzed using repeated measures random regression analysis. Analyses also done to ensure that groups did not differ in tx response by center (Boston, Cincinnati and Minneapolis). | Score: | NR | Binge frequency: | HDRS, mean (SD): | HDRS, mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD): | BMI:
Hudson et al., 1998 | To assess the efficacy of the SSRI fluvoxamine in treating patients with BED in a three-center randomized placebo-controlled trial. | G1: Fluvoxamine (N = 42) | G1: 41.2 (9.9) | Met draft criteria for BED from the DSM IV, had to have reported a hx of at least 3 BEs per wk for at least 6 mos. Binge defined using DSM IV criteria and the number of calories consumed had to be at least 1500 kcal., had to be aged 18–60, had to wt > 85% of the midpoint of IDW for height. | | | Fair | | G1: NR (P = NR) | G1: 4.4 (3.6) | G1: NR (P = NR) | G1: 34.2 (6.0) | G1: NR (P = NR)
Setting: | | G2: Placebo (N = 43) | G2: 43.0 (9.5) | Exclusion: | | | Intent to treat: | | G2: NR (P = NR) | G2: 4.1 (3.7) | G2: NR (P = NR) | G2: 36.8 (8.2) | G2: NR (P = NR)
Outpatient, Harvard Medical School/McLean Hospital, University of Cincinnati and University of Minnesota, USA | | Enrollment: | (P = NS) | Pregnant, lactating, displayed concurrent AN, concurrent or recent (last 1 yr) major depression or obsessive compulsive disorder or lifetime substance abuse, psychosis, mania, or organic dementia, posed a sig suicide risk and received psychotherapy or behavior therapy within 3 mos prior to entry into study, hx of psychosurgery or seizures, hx of any psychiatric disorder that could interfere with diagnostic assessment, tx or compliance, clinically unstable medical illness, clinically sig abnormal lab results, received monoamine oxidase inhibitors, tricyclics, neuroleptics, lithium or fluoxetine in the four wks before randomization, had received investigational meds or depot neuroleptics within 3 mos before randomization and had previously received fluvoxamine. | | | Yes | | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR)
Enrollment period: | | - 115 patients entered study; - 85 randomly assigned (Boston = 26; Cincinnati = 30; Minnesota = 29); - 10 participants withdrew before end of 4 wks; - Another 8 participants withdrew between wks 4 and 9; - 67 patients completed 9 wks of tx (a sigly greater proportion of patients treated with fluvoxamine discontinued tx because of an adverse medical event or for any reason) | Sex: | | | | Blinding: | | Diff between groups in change over time (P < 0.006) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P < 0.04)
February to September 1993 | | | Female: | | | | Double | | G1 sig greater rate of reduction than G2 | | | | G1 sig greater rate of reduction than G2
| | | G1: 93% | | | | Adverse events: | | Remission (ITT):
| | | G2: 88% | | | | A sig greater percentage of patients receiving fluvoxamine experienced insomnia, nausea and abnormal dreams when compared with patients receiving placebo. The commonly reported adverse events included insomnia, headache, nausea, asthenia, depression, dizziness, somnolence, abnormal dreams, dry mouth, nervousness, and decreased libido. | | G1: 38% (P = NR)
| | | (P = NS) | | | | Funding: | | G2: 26% (P = NR)
| | | Race/ethnicity: | | | | The Upjohn Co. and Solvay Pharmaceuticals | | Diff between groups (P = NS)
| | | Caucasian: | | | | | | Diff between groups in change over time (P = NR)
| | | G1: 98% | | | | | | Remission (9 wk completers):
| | | G2: 95% | | | | | | G1: 45% (P = NR)
| | | (P = NS) | | | | | | G2: 24% (P = NR)
| | | Hx of major depression: | | | | | | Diff between groups (P = 0.04)
| | | G1: 48% | | | | | | Diff between groups in change over time (P = NR)
| | | G2: 28% | | | | | | Remission (> 4 wk completers):
| | | (P = NS) | | | | | | G1: 44% (P = NR)
| | | | | | | | | G2: 24% (P = NR)
| | | | | | | | | Diff between groups (P = 0.04)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | | | CGI severity scale:
| | | | | | | | | | | G1: NR (P = NR)
| | | | | | | | | | | G2: NR (P = NR)
| | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in changeover time (P < 0.002)
| | | | | | | | | | | G1 sig greater rate of reductionthan G2.
| | | | | | | | | | | CGI Improvement scale:
| | | | | | | | | | | G1: NR (P = NR)
| | | | | | | | | | | G2: NR (P = NR)
| | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in changeover time (P < 0.002)
| | | | | | | | | | | G1 sig greater rate of increasethan G2
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | 8 wks of imipramine (25 mg 3X/day TID) or placebo. | Repeated measures ANOVA using Bonferroni/Dunn corrections. Fisher PLSD t test (Post-hoc) where appropriate. | Score: | | Estimate is change from baseline, mean (SD) | | Estimate is change over time (SD) | | Estimate is change over time (SD)
Laederach-Hoffman et al., 1999 | 1) To determine if a combination of imipramine and diet counseling with psych support is more effective in treating obese binge eaters than placebo and diet counseling with psych support.; 2) If wt loss achieved during the 8 wks of drug therapy is maintained for subsequent 6 mos, with diet counseling and psyc support continuing during this time. | G1: imipramine (25 mg T.I.D.) (N = 15) | G1: 40.7 (10.9) | BED per DSM IV, overwt or obese defined as BMI > 27.5 kg/m^2^, age: 20–60. | Diet counseling - 30 minutes of individual diet counseling by a dietitian biwkly. | | Fair | BE, mean (SD): | BE, mean | SDS (SD): | SDS: | Body Weight Index kg/m ^ 2 ^ , mean (SD): | Body Weight Index:
Setting: | | G2: placebo (N = 16) | G2: 35.7 (10.3) | Exclusion: | Psych Support - behavioral oriented: | | Intent to treat: | G1: 7.1 (4.1) | 8 wks: | G1: 35.3 (6.3) | G1: 28.9 (5.8) | G1: 36.1 (6.3) | G1: NR
Counseling center for wt problems - Medical Outpatient Clinic of the University of Berne, Switzerland | | Enrollment: | (P = NS) | Endocrine disorder, diabetes mellitus, pregnancy, arterial hypertension, renal diseases, pulmonary diseases (chronic obstructive lung disease, bronchial asthma, etc), use of psychoactive meds or appetite suppressants, contraindications for drugs with anticholinergic side effects, psychiatric disorders including cyclothymia, schizophrenia, major depression, personality disorders, concomitant psychotherapy, and other eating disorders including BN (fulfilling all DSM IV criteria) and AN | 1) individual 15–35 minutes sessions biwkly; 2) group therapy for 1.5 hours (N = 10–14) moly guided by an assistant dietitian. Diet counseling and psych support continued for 6 mos. | | No | G2: 7.1 (4.1) | G1: -4.5 (4.2) (P < 0.001) | G2: 35.0 (5.8) | (P = NS) | G2: 43.2 (9.4) | G2: NR
Enrollment period: | | - 500 med records screened; - 100 records fit criteria; - 31 agreed to participate and randomized; - 29 completed | Sex: | | | | Blinding: | (P = NS) | G2: -1.7 (2.9) (P = NS) | (P = NS) | G2: 30.8 (7.3) | (P < 0.02)
NR | | | Female: 27/31 | | | | Double | | (P = NR) | | (P = NS)
| | | Race/ethnicity: | | | | Adverse events: | | Diff between groups in change over time (P < 0.02) | | Diff between groups (P = NS)
| | | NR | | | | 2 patients dropped out due to side effects. One G2 patient complained of hunger, sweating, palpitations, arrhythmia, and general malaise. One G1 had skin eruptions and an aversion to tablet intake. After 8 wks, no diff in total number of adverse side effects using the patient termination report score. However, anticholinergic effects (constipation, dry mouth, blurred vision) were more often reported in imipramine group (7 vs 3 times, P < 0.05). | | G1 better than G2 | | Diff between groups in change over time (P = NS)
| | | Systolic BP, mean (SD): | | | | Funding: | | 32 wks:
| | | G1: 132.3 (18.0) | | | | NR | | G1: -3.2 (2.9)
| | | G2: 131.4 (13.5) | | | | | | G2: 0.0 (1.4)
| | | (P = NS) | | | | | | (P = NR)
| | | Diastolic BP, mean (SD): | | | | | | Diff between groups in change over time (P = 0.0001)
| | | G1: 87.0 (9.4) | | | | | | G1 better than G2
| | | G2: 87.5 (9.1) | | | | | | | | | Body Wt, kg, mean(SD): | Wt change, kg, mean:
| | | (P = NS) | | | | | | | | | G1: 96.0 (14.2) | 8 wks:
| | | | | | | | | | | | G2: 114.8 (29.5) | G1: -2.1 (1.7) (P = NR)
| | | | | | | | | | | | (P < 0.05) | G2: 0.2 (3.3) (P = NR)
| | | | | | | | | | | | | Diff between groups in changeover time (P < 0.05)
| | | | | | | | | | | | | G1 better than G2
| | | | | | | | | | | | | 32 wks:
| | | | | | | | | | | | | G1: -5.0 (2.8) (P < 0.01)
| | | | | | | | | | | | | G1: -5.0 (2.8) (P < 0.01)
| | | | | | | | | | | | | G2: + 2.1 (6.8) (P = NS)
| | | | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | | | Diff between groups in change over time (P = 0.0002)
| | | | | | | | | | | | | G1 better than G2
| | | | | | | | | | HAM-D, mean (SD): | HAM-D, mean (SD): | Waist Hi P Ratio (SD):
| | | | | | | | | | G1: 22.6 (9.8) | 8 wks: | G1: 0.96 (0.07)
| | | | | | | | | | G2: 21.3 (12.0) | G1: -9.6 (7.1) (P < 0.001) | G2: 1.01 (0.07)
| | | | | | | | | | (P = NS) | G2: -3.5 (8.9) (P = NR) | (P = NS)
| | | | | | | | | | | Diff between groups (P = 0.02)
| | | | | | | | | | | G1 better than G2
| | | | | | | | | | | 32 wks:
| | | | | | | | | | | G1: -6.8 (5.0) (P < 0.01)
| | | | | | | | | | | G2: 0.0 (4.9) (P < 0.01)
| | | | | | | | | | | (P = NR)
| | | | | | | | | | | Diff between groups in change over time (P < 0.0001)
| | | | | | | | | | | G1 better than G2
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | 2–5 wk screening period, followed by 14-wk tx period (topiramate flexible-dose 25 mg– 600mg/d; median 212mg/d) and 2-wk taper and discontinuation period. Patients evaluated at least twice during screening period and after wks 1, 2, 4, 6, 8, 10 and 14 during tx. They were seen at the end of wks 15 and 16 during discontinuation. For primary efficacy measure, patients given take-home diaries at each visit and asked to record binges and meds (once begun). Study meds provided in pre-packaged bottles that were identical for placebo and meds. | Baseline characteristics compared using Fisher's exact test and t test. For primary analyses, used repeated measures random regression analyses. Also, nonparametric Wilcoxon rank sum test used to compare change from baseline for each group. | Score: | Binge frequency per wk: | Reduction in binge frequency per wk: | CGI severity, mean (SD): | CGI severity, mean (SD): | BMI kg/m ^ 2 ^ , mean (SD): | BMI:
McElroy, Arnold et al., 2003 | To assess the efficacy of topiramate in the tx of BED associated with obesity. | G1: Topiramate (N = 30) | G1: 40.9 (8.2) | Aged 18–60, DSM IV TR criteria for BED; obese (BMI > 30 kg/m2) and score > 15 on YBOCS-BE. | | | Fair | G1: 5.3 (2.8) | G1: 94% | G1: 4.7 (0.9) | G1: NR | G1: 44.2 (7.1) | G1: NR
Setting: | | G2: Placebo (N = 31) | G2: 40.7 (9.1) | Exclusion: | | | Intent to treat: | G2: 6.3 (2.8) | G2: 46% | G2: 4.9 (0.8) | G2: NR | G2: 42.0 (6.7) | G2: NR
Outpatient, University of Cincinnati Medical Center, USA | | Enrollment: | (P = NS) | 1) substance use disorder (DSM IV TR) within the last 6 mos, 2) unstable bipolar disorder (DSM IV TR) within the past 3 mos, 3) clinically sig suicidality, 4) any current or past psychiatric disorder that could interfere with diagnostic assessment, tx or adherence, 5) clinically unstable medical illness, 6) hx of nephrolithiasis or seizures, 7) clinically sig abnormal laboratory results, 8) need for tx with any meds that might adversely interact with or obscure the action of topiramate, 9) tx with psychoactive meds within two wks of random assignment, 10) tx with an experimental drug or an experimental device within 30 days of random assignment, or 11) previous tx with topiramate. | | | Yes | (P = NS) | Diff between groups (P = NS) | (P = NS) | Diff between groups (P = 0.01) | | (P = NR)
Enrollment period: | | - 98 individuals were screened; - 61 participants met criteria and agreed to participate; - 35 participants completed 14 wks of tx | Sex: | | | | Blinding: | | Diff between groups in change over time (P = 0.02) | | Diff between groups in rate of change (P < 0.02) | | Diff between groups in rate of change (P < 0.003)
Sept., 1998 through June, 2000 | | | NR | | | | Double | | Diff between groups in rate of change (P < 0.0004) | | G1 greater improvement than G2 | | G1 greater improvement than G2
| | | Race/ethnicity: | | | | Adverse events: | | G1 greater reduction than G2
| | | NR | | | | 9 individuals withdrew because of adverse events (G1 = 6; G2 = 3) | Binge day frequency per wk: | Reduction in binge day frequency per wk: | HDRS, mean (SD): | HDRS, mean (SD): | Wt kgs, mean (SD): | Wt loss, kg, mean:
| | | | | | | G1: headache, paresthesias and amenorrhea. | G1: 4.3 (1.8) | G1: 93% | G1:5.9 (5.1) | G1: NR | G1:120.4 (18.8) | G1: 5.9
| | | | | | | G2: leg cramps, sedation and testicular soreness. Adverse events among individuals who continued in the study were reported to be “mild” or “moderate” and “resolved with time or dose reduction”. | G2: 4.8 (1.8) | G2: 46% | G2: 5.8 (4.8) | G2: NR | G2: 123.4 (24.4) | G2: 1.2
| | | | | | | Funding: | (P = NS) | Diff between groups (P = NS) | (P = NS) | (P = NR) | | (P = NR)
| | | | | | | Ortho McNeill Pharmaceutical | | Diff between groups in change over time (P = 0.02) | | Diff between groups in change over time (P = NS) | | Diff between groups in rateof change (P < 0.005)
| | | | | | | | | Diff between groups in rate of change (P < 0.0001) | | | | G1 greater improvementthan G2
| | | | | | | | | G1 greater reduction than G2
| | | | | | | | YBOCS-BE total, mean (SD): | YBOCS-BE total, mean (SD):
| | | | | | | | G1: 21.5 (3.9) | G1: NR
| | | | | | | | G2: 21.6 (4.6) | G2: NR
| | | | | | | | (P = NS) | (P = NR)
| | | | | | | | | Diff between groups in rate of change (P < 0.004)
| | | | | | | | | G1 greater improvement than G2
| | | | | | | | YBOCS-BE Obsessions, mean (SD): | YBOCS-BE Obsessions, mean (SD):
| | | | | | | | G1: 10.5 (2.1) | G1: NR
| | | | | | | | G2: 10.7 (2.4) | G2: NR
| | | | | | | | (P = NS) | (P = NR)
| | | | | | | | | Diff between groups in rate of change (P < 0.04)
| | | | | | | | | G1 greater improvement than G2
| | | | | | | | YBOCS-BE Compulsions, mean (SD): | YBOCS-BE Compulsions, mean (SD):
| | | | | | | | G1: 11.0 (2.1) | G1: NR
| | | | | | | | G2: 10.7 (2.4) | G2: NR
| | | | | | | | (P = NS) | (P = NR)
| | | | | | | | | Diff between groups in rate of change (P < 0.0008)
| | | | | | | | | G1 greater improvement than G2
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | 1 wk of single-blind placebo administration followed by randomization to sertraline or placebo group for 6 wks. Tx dose began at 1 capsule of 50mg/day for at least 3 days; after, adjusted as tolerated to between 1 to 4 capsules daily. Mean end of study dose in G1: 187 mg (SD = 30). | Except for response category, repeated measures random regression analyses used to assess outcomes, using tx-by-time as the effect measure. | Score: | Binges/wk, mean (SD): | Binges/wk, mean (SD): | HDRS (SD): | HDRS: | BMI, kg/m^2^, mean (SD): | BMI, kg/m^2^:
McElroy et al., 2000 | Placebo-controlled trial to assess the efficacy of the SSRI sertraline in the tx of BED. | G1: Sertraline (N = 18) | G1: 43.1 (9.9) | DSM IV criteria for BED and had experienced ≥ 3 BE/wk for at least prior 6 mos; BE defined by DSM IV criteria plus required size at least 1500 kcal 18–60 yrs wt > 85% of IBW. | Subjects monitored binges using diaries. Wkly clinical interviews assessed binges since last visit, CGI ratings, meds dose, and wt. At wks 0, 2, 4, 6, HDRS was administered. | Binge frequency was analyzed using logarithmic transformation to stabilize variance. | Good | G1: 7.6 (4.8) | G1: 1.13 (1.56) (P = NR) | G1: 6.4 (3.9) | G1: NR (P = NR) | G1: 36.4 (7.4) | G1: NR (P = NR)
Setting: | | G2: Placebo (N = 16) | G2: 41.0 (12.2) | Exclusion: | | Response category diff compared by exact trend test for two-by-k-ordered tables. | Intent to treat: | G2: 7.2 (5.8) | G2: 3.85 (3.81) (P = NR) | G2: 7.5 (8.4) | G2: NR (P = NR) | G2: 35.8 (7.5) | G2: NR (P = NR)
Outpatient; single center; USA | | Enrollment: | (P = NS) | Current AN dx; substance use disorder within past 6 mos; hx of psychosis or mania; risk of suicide; use of psychotropics within 2 wks of randomization; previous use of sertraline; < 3 binges in the wk prior to randomization. | | | Yes | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR)
Enrollment period: | | - 34 randomized and enrolled; - 26 (13 in each group) completed 6 wks tx | Sex: | | | | Blinding: | | Diff between groups in change over time (P = 0.008) | | Diff between groups in change over time (SE): 1.33 (1.00) | | Diff between groups in change over time (SE): -0.596 (0.189) (P = 0.002)
NR | | | G1: Female: 89% | | | | Single-blind placebo administration; double-blind randomization and tx | | G1 better than G2 | | (P = NS) | | G1 better than G2
| | | G2: Female: 100% | | | | Adverse events: | | Frequency of binges:
| | | (P = NS) | | | | No subjects withdrew due to adverse events | | Percentage decrease measured by categorical change in response:
| | | Race/ethnicity: | | | | Participants experiencing insomnia: | | Remission or cessation of binges: G1:7; G2: 2
| | | NR | | | | G1: 7 (39%) | | Marked = 75%–99% decrease: G1: 2; G2:3
| | | Current major depressive disorder: | | | | G2: 1 (6%) | | Moderate = 50%–74% decrease: G1: 3; G2: 4
| | | G1: 17% | | | | (P = 0.04) | | None = < 50% decrease: G1: 0; G2: 4
| | | G2: 19% | | | | Funding: | | Diff between groups in change over time (P = NS)
| | | (P = NS) | | | | In part by Pfizer, Inc. | | | | CGI score:
| | | Lifetime majordepressive disorder: | | | | | | | | Severity
| | | G1: 61% | | | | | | | | G1: NR (P = NR)
| | | G2: 44% | | | | | | | | G2: NR (P = NR)
| | | (P = NS) | | | | | | | | Diff between groups (P = NR) diff between groups in change over time (SE): -1.007 (0.183)
| | | | | | | | | | | (P < 0.001)
| | | | | | | | | | | G1 better than G2
| | | | | | | | | | | CGI score:
| | | | | | | | | | | Improvement:
| | | | | | | | | | | G1: NR (P = NR)
| | | | | | | | | | | G2: NR (P = NR)
| | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in change over time (SE): 0.929 (0.230) (P < 0.001)
| | | | | | | | | | | G1 better than G2
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | 1 wk of single-blind placebo administration, followed by random assignment to citalopram or placebo for 6 wks. Randomized tx began with 20 mg/day for first 7 days; increased as tolerated to 40 mg/day for 7 days, and then 60 mg/day for remainder of study. Meds could be reduced to min of 1 capsule (20 mg) daily if intolerable side effects at any time during tx period. End of study dose in G1 and G2 60 mg for 17 subjects and 40 mg for 2 subjects in each group. | Repeated-measures random regression analyses, sometimes referred to as mixed-model repeated-measures analyses. | Score: | Binges/wk, mean (SD): | Binges/wk, mean (SD): | CGI-S, mean (SD): | CGI-S, mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD):
McElroy, Hudson et al., 2003 | Placebo-controlled, randomized trial to assess the safety and efficacy of citalopram (Celexa), an SSRI, in BED | G1: Citalopram (N = 19) | G1: 42.0 (9.0) | Met DSM IV criteria for BED and had also experienced ≥ 3 binge-eating episodes wkly for at least the prior 6 mos; 18 to 60 yrs; wt > 85% of IBW. | Subjects monitored binges and meds through diaries. Binge defined using DSM IV criteria, assessed via wkly clinical interview and subjects' diaries. Diaries recorded binges, duration of binges, food consumed during binges. | | Fair | G1: 5.2 (3.6) | G1: 1.7 (3.1) | G1: 4.5 (0.7) | G1: 2.4 (1.4) | G1: 41.4 (6.9) | G1: 40.9 (7.0)
Setting: | | G2: Placebo (N = 19) | G2: 39.2 (12.0) | Exclusion: | | | Intent to treat: | G2: 5.7 (2.6) | G2: 3.4 (3.0) | G2: 5.0 (0.7) | G2: 3.6 (1.7) | G2: 34.2 (7.4) | G2: 35.7 (7.5)
Single center; outpatient; USA | | Enrollment: | (P = NS) | Pregnant or lactating; concurrent AN or BN; concurrent or recent (within 1 yr of study entry) substance abuse or dependence: lifetime hx of psychosis, mania or hypomania, or dementia: hx of any psychiatric disorder that could interfere with diagnostic assessment, tx, or compliance: posed a sig suicide risk; received psychotherapy or behavioral therapy within 3 mos of entry into study; clinically unstable medical illness; hx of seizures; clinically sig laboratory abnormalities; received monoamine oxidase inhibitors within 4 wks of randomization; received other psychotropic meds within 2 wks of randomization; received investigational meds or depot neuroleptics within 3 mos of randomization; previously treated with citalopram; experienced < 3 binges in the wk before randomization (i.e., were considered placebo responders). | | | Yes | (P = NS) | Change over time from baseline to wk 6: -0.375 (0.222) (P = NS) | (P = 0.03) | Change over time from baseline to wk 6: | (P = 0.003) | Change over time from baseline to wk 6: -0.818 (0.254)
Enrollment period: | | - 50 screened who were recruited through advertisements (12 of these did not meet criteria and were not enrolled); - 38 enrolled (19 assigned to each group); - 31 after 4 wks | Sex: | | | | Blinding: | | Rate of change: -0.311 (0.086) (P = 0.003) | | (P = NS) | | (P = 0.001)
August 2000 through July 2001 | | | Female: 95% | | | | Double | | G1 better than G2 | | Rate of change: -0.475 (0.217) | | Rate of change: -0.525 (0.145)
| | | (P = NS) | | | | Adverse events: | | | | (P = 0.028) | | (P < 0.001)
| | | Race/Ethnicity: | | | | Sweating (P = 0.008), fatigue (P = 0.046), dry mouth, headache, diarrhea, nausea, sedation, insomnia, sexual dysfunction (P = NS) | | | | G1 better than G2 | | G1 greater than G2
| | | White: | | | | Funding: | Binge days/wkfrequency, mean (SD): | Binge days/wk, mean (SD): | HAM-D, mean (SD): | HAM-D, mean (SD): | Wt, kg, mean (SD): | Wt, kg, mean (SD):
| | | G1: 79% | | | | In part by Forest Laboratories | G1: 4.0 (1.7) | G1: 1.2 (2.0) | G1: 3.1 (3.2) | G1: 1.4 (2.3) | G1: 116.8 (21.0) | G1: 114.1 (22.4)
| | | G2: 95% | | | | | G2: 4.0 (1.5) | G2: 2.8 (2.2) | G2: 2.7 (3.7) | G2: 1.9 (3.1) | G2: 94.6 (23.2) | G2:99.8 (24.7)
| | | (P = NS) | | | | | (P = NS) | Change over time from baseline to wk 6: -0.488 (0.199) (P = 0.016) | (P = NS) | Change from baseline to wk 6 | (P = 0.004) | Change over time from baseline to wk 6:-2.49 (0.66) (P < 0.001)
| | | Current major depressive disorder: | | | | | | G1 better than G2 | | (P = NS) | | G1 better than G2
| | | G1: 21% | | | | | | Rate of change: -0.324 (0.076) (P = < 0.001) | | Rate of change: -1.05 (0.54) | | Rate of change: -1.43 (0.40)
| | | G2: 42% | | | | | | Frequency of binges: | | (P = 0.05) | | (P < 0.001)
| | | (P = NS) | | | | | | Percentage decrease measured by categorical change. diffbetween remission (cessation of binges): | | G1 better than G2 | | G1 better than G2
| | | Lifetime major depressive disorder: | | | | | | - marked (75%–99% decrease); - moderate (50%–74% decrease); - none ( < 50% decrease)
| | | G1: 63% | | | | | | (P = NS)
| | | G2: 74% | | | | | YBOCS-BE score | YBOCS-BE score | | | | Interaction effects:
| | | (P = NS) | | | | | Total, mean (SD): | Total: | | | | No differential effects in subjects with and without current major depressive disorder or by varying BMI at baseline
| | | | | | | | G1: 19.4 (4.2) | G1: 7.6 (7.2)
| | | | | | | | G2: 18.5 (3.1) | G2: 13.2 (5.9)
| | | | | | | | (P = NS) | Change over time from baseline to wk 6:-5.73 (2.33) (P = 0.007)
| | | | | | | | | G1 better than G2
| | | | | | | | | Rate of change: -3.73 (1.37) (P = 0.007)
| | | | | | | | | G1 better than G2
| | | | | | | | YBOCS-BE score | YBOCS-BE Score
| | | | | | | | Obsessions, mean (SD): | Obsessions:
| | | | | | | | G1: 9.3 (2.2) | G1: 4.3 (3.6)
| | | | | | | | G2: 9.3 (1.8) | G2: 6.8 (2.6)
| | | | | | | | (P = NS) | Change over time from baseline to wk 6: -2.48 (1.22) (P = 0.04)
| | | | | | | | | G1 better than G2
| | | | | | | | | Rate of change: -1.44 (0.72) (P = 0.05)
| | | | | | | | | G1 better than G2
| | | | | | | | YBOCS-BE score | YBOCS-BE Score
| | | | | | | | Compulsions, mean (SD): | Compulsions:
| | | | | | | | G1: 10.1 (2.2) | G1: 3.4 (3.9)
| | | | | | | | G2: 9.2 (1.7) | G2: 6.4 (3.6)
| | | | | | | | (P = NS) | Rate of change: -2.26 (0.72) (P = 0.002)
| | | | | | | | | G1 better than G2
| | | | | | | | | Change over time from baseline to wk 6: -2.88 (1.27) (P = 0.02)
| | | | | | | | | G1 better than G2
Author, yr: | Research objective: | Groups: | Age, yrs, mean: | Inclusion: | Prior to tx, all subjects completed two intake assessment sessions, 1 wk apart. At the first, BED dx was confirmed using EDE, and subjects instructed on completing food logs; At the second, the SCID, HAM-D, and CGI were administered, and SCL-90 and BDI were completed. | Independent samples t-tests to measure between-group change. | Score: | Number of days with binges, past 28 days, mean (SD): | Number of days with binges, past 28 days, mean (SD): | BDI, means per item (SD): | BDI, means (SD): | Wt, lbs, mean (SD): | Wt, lbs, mean (SD):
Pearlstein et al., 2003 | To replicate the findings of previous double-blind RCT of fluvoxamine on BED. This trial was 12 wks rather than 9 and used EDE to classify BE; to assess tx effects on associated ED psychopathology as measured by EDE. | G1: Fluvoxamine (N = 9) | 41.0 | DSM IV research criteria for BED based on EDE | After 1 wk of single-blind placebo, subjects randomized to flexible dose tx or placebo; tx was titrated up to 150 mg b.i.d. Avg dose for tx was 239 mg/day, 264 mg/day for placebo. | Repeated measures ANOVAs to determine effect of tx on outcome variables after trial end. | Good | G1: 14.67 (55.68) | G1: 3.11 (4.20) | G1: 0.44 (0.22) | G1: 0.32 (0.30) | G1: 243 (85) | G1:242 (82)
Setting: | | G2: Placebo (N = 11) | Sex: | Exclusion: | Tx lasted 12 wks; first 6 wks, subjects met wkly with research nurse and psychiatrist, and biwkly for final 6 wks. Visits included collecting food logs, vital signs, noting adverse events, distributing materials on healthy eating, distributing study meds, determining dosage by response and tolerability. | | Intent to treat: | G2: 20.00 (6.21) | G2: 7.31 (9.31) | G2: 0.68 (0.57) | G2: 0.37 (0.26) | G2: 258 (96) | G2: 262 (99)
Outpatient program; single center; USA | | Enrollment: | Female: 17 | NR | At wk 12, subjects received EDE and HAM-D by blinded- interview, and completed self-report questionnaires. Post-study, subjects offered continued tx. | | NR | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR)
Enrollment period: | | - 25 recruited via ads and referral; - 25 screened; - 20 completed | Male: 3 | | | | Blinding: | Binge frequency: | Change over time for both groups (P < 0.001) | | Change over time for both groups (P < 0.01) | | Change over time for both groups (P = NS)
NR | | | Race/ethnicity: | | | | Double | G1: NR | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | Caucasian: 90% | | | | Adverse events, N: | G2: NR
| | | Marital status: | | | | In study completers: | (P = NS)
| | | Currently married: 70% | | | | Sedation: | EDE Restraint, mean (SD): | EDE Restraint, mean (SD): | HAM-D, mean (SD): | HAM-D, mean (SD):
| | | Employment status: | | | | G1: 8 | G1: 2.04 (1.24) | G1: 0.91 (0.78) | G1: 10.78 (9.22) | G1: 9.38 (9.71)
| | | Currently employed: 90% | | | | G2: 3 | G2: 1.60 (1.08) | G2: 1.45 (0.98) | G2: 14.27 (12.40) | G2: 7.38 (9.71)
| | | Avg BMI (kg/m^2^): | | | | Nausea: | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR)
| | | 41.16 | | | | G1: 4 | | Change over time for both groups (P = NS) | | Change over time for both groups (P = NS)
| | | | | | | G2: 1 | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | Dry mouth: | EDE Eating Concern, mean (SD): | EDE Eating Concern, mean (SD): | SCL-90, mean (SD): | SCL-90, mean (SD):
| | | | | | | G1: 4 | G1: 1.10 (0.96) | G1: 0.31 (0.39) | G1: 0.62 (0.33) | G1: 0.30 (0.29)
| | | | | | | G2: 3 | G2: 1.82 (1.02) | G2: 0.44 (0.55) | G2: 0.85 (0.55) | G2: 0.40 (0.29)
| | | | | | | Decreased libido: | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR)
| | | | | | | G1: 3 | | Change over time for both groups (P < 0.001) | | Change over time for both groups (P < 0.001)
| | | | | | | G2: 0 | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | Funding: | EDE Shape Concern, mean (SD): | EDE Shape Concern, mean (SD):
| | | | | | | Solvay Pharmaceuticals | G1: 3.38 (0.74) | G1: 2.24 (0.85)
| | | | | | | | G2: 3.56 (0.43) | G2: 2.50 (1.15)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Change over time for both groups (P < 0.001)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE Wt Concern, mean (SD): | EDE Wt Concern, mean (SD):
| | | | | | | | G1: 3.73 (0.49) | G1: 2.40 (1.22)
| | | | | | | | G2: 3.32 (0.94) | G2: 2.36 (1.07)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Change over time for both groups (P < 0.001)
| | | | | | | | | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Placebo for 4 wks. Only patients who continued to meet criteria (binges on at least 2 days per wk) were randomized. Patients in the meds group received 15 mg of d-fenfluramine once a day for the first wk, twice a day for the next 6 wks and once a day for the eighth wk. | Sig of the diff in the two groups tested by student's t test. Multiple linear regression analyses used to test for sig grp diff while controlling for baseline depression and wt. | Score: | Binges per wk, mean (SD): | Binges per wk, mean (SD): | BDI, mean (SD): | Change BDI, mean (SD): | Wt lbs, mean (SD): | Change wt lbs, mean (SD):
Stunkard et al., 1996 | RCT investigating use of d-fenfluramine for tx of BED | G1: d-fenfluramine (N = 14) | NR | Met criteria for BED established by Spitzer et al. (1992) and used in DSM IV; female. | | Slopes reported for change in binge days; eating inventory, eating habits checklist; but no values at FU intervals reported. | Fair | G1: 2.2 (1.3) | Post tx: | G1: 15.31 (8.18) | G1: -0.21 (0.50) | G1: 238.30 (50.20) | G1: -0.02 (0.93)
Setting: | | G2: placebo (N = 14) | Sex: | Exclusion: | | | Intent to treat: | G2: 2.3 (2.0) | G1: 0.6 (1.0) (P = 0.0001) | G2: 9.76 (9.75) | G2: -0.04 (0.46) | G2: 210.0 (33.80) | G2: 0.06 (0.70)
Outpatient, Wt and Eating Disorders Program, University of Pennsylvania, Philadelphia, PA, USA | | Enrollment: | Female: 100% | None | | | NR | (P = NS) | G2: 2.3 (2.9) (P = NS) | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR)
Enrollment period: | | - 1450 screened using two-stage procedure (structured telephone interview followed by face-to-face interview); - 50 met criteria; - All received placebo for 4 wks; - After 4 wks, only 28 continued to meet criteria; - 14 randomly assigned to each of the two groups; - 2 from each group dropped out in the first two wks of tx | Race/ethnicity: | | | | Blinding: | | Diff between groups (P = NR) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
NR | | | NR | | | | Double | | Diff between groups in change over time (P = 0.02)
| | | Binges per wk in the first wk, mean (SD): | | | | Adverse events: | | G1 better than G2
| | | G1: 2.2 (1.3) | | | | Reported for patients in both groups. Headache and diarrhea more common in meds than placebo grp. For one patient in drug grp, moderately severe rash reported which went away 3 mos after discontinuation of drug. | | Diff between groups in change over time (controlling for baseline wt and depression scores) (P = 0.01)
| | | G2: 2.3 (2.0) | | | | Funding: | | 1 mo FU:
| | | BMI, kg/m2, mean (SD): | | | | Servier Amerique and NIMH | | G1: 1.3
| | | (N = 22) | | | | | | G2: 1.1
| | | 36.7 (5.8) | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 4 mo FU:
| | | | | | | | | G1: 1.8
| | | | | | | | | G2: 1.3
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Binge days per wk, mean (SD): | Change binge days per wk, mean (SD):
| | | | | | | | G1: 2.45 (1.00) | G1: -0.24 (0.13)
| | | | | | | | G2: 2.39 (1.32) | G2: -0.15 (0.16)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Gormally Eating Habits Checklist, mean (SD): | Change Gormally Eating Habits Checklist, mean (SD):
| | | | | | | | G1: 27.83 (10.60): | G1: -0.65 (1.04)
| | | | | | | | G2: 22.25 (8.67) | G2: -0.08 (0.73)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Eating Inventory - Restraint, mean (SD): | Change Eating Inventory - Restraint, mean (SD):
| | | | | | | | G1: 9.63 (5.91) | G1: 0.23 (0.52)
| | | | | | | | G2: 9.16 (3.76) | G2: 0.14 (0.37)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Eating Inventory-Disinhibition, mean (SD): | Change Eating Inventory-Disinhibition, mean (SD):
| | | | | | | | G1: 12.80 (3.24) | G1: -0.18 (0.54)
| | | | | | | | G2: 12.17 (3.09) | G2: -0.03 (0.23)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Eating Inventory - Hunger score, mean (SD): | Change Eating Inventory - Hunger score, mean (SD):
| | | | | | | | G1: 9.51 (4.17) | G1: -0.15 (0.46)
| | | | | | | | G2: 8.56 (3.05) | G2: 0.02 (0.19)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Abstinence % (completers):
| | | | | | | | | G1: 80%
| | | | | | | | | G2: 33%
| | | | | | | | | Diff between groups (P = NR)

Evidence Table 11. Medication plus behavioral intervention trials for binge eating disorder

| | | | | | | | Eating Related Measures | | Psychological/Psychiatric Measures | | Biomarkers
Study Description | Objective | Design | Patient Characteristics | Inclusion/Exclusion Criteria | Treatment | Statistical Methods | Quality | Baseline | Outcomes | Baseline | Outcomes | Baseline | Outcomes
Author, yr: | Research objective: | Groups: | Age yrs, mean (SD) (range): | Inclusion: | G1: Wt loss-30 90-minutes group sessions wkly for the first 24 wks and then bi-wkly. Based on modified LEARN program (without BE materials). Focus on gradual lifestyle changes. | Repeated measures ANOVA followed by ANCOVAs (controlling for baseline characteristics) at each time point. Pairwise comparisons to determine diff between groups. | Score: | Binges/wk, mean (SD): | Binges/wk, mean (SD): | BDI, mean (SD): | BDI, mean (SD): | Wt, kg, mean (SD): | Wt, kg, mean (SD):
Agras et al., 1994 | To compare the effects of wt loss tx, CBT, and desipramine on binge eating and wt in a 3 group additive design in overwt participants with BED. | G1: wt loss therapy for 9 mos (N = 37) | 45.0 (10) (22 – 65) | DSM IV criteria for BED | G2: CBT based on manual by Telch et al., for BED for 12 wkly sessions. Followed by 18 sessions of the wt loss therapy as described above. | At wk 12, analysis of G2 and G3 are combined. | Fair | G1: 4.5 (1.6) | 12 wks: | G1: 12.9 (6.5) | 12 wks: | G1: 102.9 (15.8) | 12 wks:
Setting: | | G2: CBT for 3 mos followed by wt loss therapy for 6 mos (CBT/WL) (N = 36) | (P = NR) | Exclusion: | G3: Following completion of CBT, received desipramine and wt loss therapy. Seen in small groups immediately before or after wt loss groups (wkly for first 4 wks, bi-wkly for 4 wks, and then at 4-wk intervals). Groups conducted by psychiatrist who explained meds. Began on 25 mg and dose increased depending on side effects and therapeutic effects to a max dose of 300 mg. Discontinued over a 2-wk period following post-tx assessment. Mean dose 285 mg with a mean blood level of 212 ng/mL. | | Intent to treat: | G2: 4.4 (1.4) | G1: 2.5 (1.9) | G2: 13.5 (7.8) | G1: 11.6 (8.0) | G2: 102.1 (15.7) | G1: 100.9 (16.8) (P = NR)
Outpatient, Stanford University, CA, USA | | G3: CBT for 3 mos followed by both wt loss therapy and desipramine for 6 mos (CBT/WL-D) (N = 36) | Sex: | Current involvement in a wt loss program, currently taking antidepressant meds or any meds that might influence wt, sufficient suicidality that may make outpt tx with desipramine dangerous, drug/alcohol abuse, hx of purging within the prior 12 mo, BMI < 27. | Assessments: baseline, wk 12, 24, 36 (Post-tx), 3-mo FU | | No | G3: 5.1 (1.4) | G2: 1.5 (1.4) | G3: 13.7 (8.1) | G2: 12.7 (9.2) | G3: 111.9 (17.4) | G2: 102.7 (16.5) (P = NR)
Enrollment period: | | Enrollment: | Female: 100% | | | | Blinding: | (P = NS) | G3: 1.8 (1.3) | (P = NS) | G3: 10.8 (8.9) | (P = NS) | G3: 112.7 (18.5) (P = NR)
NR | | Randomized: 109 | Race/ethnicity: | | | | No | | Diff between groups (P = NR) | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | Drop out, N (%): | NR | | | | Adverse events: | | Diff between groups in change over time (P < 0.01) | | Diff between groups in change over time (P = NS) | | Diff between groups (G2 + G3) vs G1 in change over time (P < 0.002)
| | G1: 10 (27%) | BMI, mean (SD): | | | | 24% discontinued desipramine before the post tx assessment because of side effects. | | G2 + G3 better than G1 | | 24 wks: | | G1 better than G2, G3
| | G2: 6 (17%) | 38.6 (6.6) | | | | Funding: | | 24 wks: | | G1: 11.2 (8.5) | | 24 wks:
| | G3: 8 (23%) | Age of onset of BE yrs, mean (SD): | | | | NIH | | G1: 1.2 (1.2) | | G2: 8.5 (6.5) | | G1: 100.4 (17.3)
| | (P = NS) | 19 (10.7) | | | | | | G2: 1.1 (1.1) | | G3: 8.6 (8.2) | | G2: 100.7 (16.7)
| | End of tx: N = 88 | (P = NR) | | | | | | G3: 1.6 (1.8) | | Diff between groups (P = NR) | | G3: 107.0 (20.1)
| | 3 mo FU: | Age of onset of overwt yrs, mean (SD): | | | | | | Diff between groups (P = NR) | | Diff between groups in change over time (P = NS) | | Diff between groups (P = NR)
| | Drop out, N: | 15.5 (10.2) | | | | | | Diff between groups in change over time (P = NS) | | 36 wks: | | Diff between groups in change over time (P = NS)
| | G1: 6 | (P = NR) | | | | | | 36 wks (Post-tx): | | G1: 11.3 (10.3) | | 36 wks:
| | G2: 5 | Education: | | | | | | G1: 1.5 (0.2) | | G2: 8.9 (7.6) | | G1: 99.2 (16.9)
| | G3: 3 | College grad: 55% | | | | | | G2: 1.2 (1.3) | | G3: 7.8 (7.8) | | G2: 100.5 (17.6)
| | | Some college: 38% | | | | | | G3: 0.9 (0.9) | | Diff between groups (P = NR) | | G3: 105.9 (20.5)
| | | | | | | | | Diff between groups (P = NR) | | Diff between groups in change over time (P = NS) | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS) | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 3 mo FU: | | | | 3 mo FU
| | | | | | | | | G1: 2.0 | | | | Wt change from baseline, kg, mean:
| | | | | | | | | G2: 1.7 | | | | G1: -4.15
| | | | | | | | | G3: 1.5 | | | | G2: 0
| | | | | | | | | Diff between groups (P = NR) | | | | G3: -4.8
| | | | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | | | Diff between groups (G2 vs G3) in change over time (P < 0.05)
| | | | | | | | | | | | | G3 better than G2
| | | | | | | | | | | | | G1 vs G2 (P = NS)
| | | | | | | | | | | | | G1 vs G3 (P = NS)
| | | | | | | | TFEQ-Disinhibition, mean (SD): | TFEQ - Disinhibition, mean (SD):
| | | | | | | | G1: 13.7 (1.8) | 12 wks:
| | | | | | | | G2: 14.0 (1.1) | G1: 12.7 (2.6)
| | | | | | | | G3: 14.6 (1.2) | G2: 12.7 (1.8)
| | | | | | | | Diff between G1 vs G3 (P < 0.03) | G3: 12.2 (2.3)
| | | | | | | | G3 higher disinhibition | Diff between groups (P = NR)
| | | | | | | | Diff between G1 vs G2(P = NS) | Diff between groups in change over time (P = NS)
| | | | | | | | Diff between G2 vs G3(P = NS) | 24 wks:
| | | | | | | | | G1: 11.7 (3.0)
| | | | | | | | | G2: 10.8 (2.7)
| | | | | | | | | G3: 9.7 (3.5)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups (G1 vs G3) in change over time (P < 0.008)
| | | | | | | | | G3 less disinhibited vs G1
| | | | | | | | | Diff between G1 vs G2 in change over time (P = NS)
| | | | | | | | | Diff between G2 vs G3 in change over time (P = NS)
| | | | | | | | | 36 wks (Post-tx):
| | | | | | | | | G1: 11.6 (2.6)
| | | | | | | | | G2: 10.8 (3.1)
| | | | | | | | | G3: 10.2 (4.2)
| | | | | | | | | (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | TFEQ-Hunger, mean (SD): | TFEQ - Hunger, mean (SD):
| | | | | | | | G1: 10.3 (2.9) | 12 wks:
| | | | | | | | G2: 9.1 (2.9) | G1: 9.4 (3.2)
| | | | | | | | G3: 10.6 (2.6) | G2: 7.8 (3.1)
| | | | | | | | Diff between groups (P = NS) | G3: 8.3 (2.4)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 24 wks:
| | | | | | | | | G1: 8.5 (3.2)
| | | | | | | | | G2: 6.2 (2.9)
| | | | | | | | | G3: 5.8 (3.1)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff groups in change over time
| | | | | | | | | G3 less hunger than G1 (P < 0.0004)
| | | | | | | | | G2 less hunger than G1(P < 0.03)
| | | | | | | | | G2 vs G3 (P = NS)
| | | | | | | | | 36 wks (Post-tx):
| | | | | | | | | G1: 8.4 (3.2)
| | | | | | | | | G2: 6.4 (3.2)
| | | | | | | | | G3: 7.2 (2.8)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | TFEQ Restraint, mean (SD): | TFEQ Restraint mean (SD):
| | | | | | | | G1: 8.7 (4.5) | 12 wks:
| | | | | | | | G2: 6.6 (2.8) | G1: 11.2 (5.1)
| | | | | | | | G3: 8.2 (3.6) | G2: 8.5 (3.5)
| | | | | | | | Diff between G1 vs G2 (P < 0.05), | G3: 10.4 (0.5)
| | | | | | | | G1 higher restraint | Diff between groups (P = NR)
| | | | | | | | Diff between G2 vs G3 (P < 0.05) | Diff between groups in change over time (P = NS)
| | | | | | | | G3 higher restraint | 24 wks:
| | | | | | | | Diff between G1 vs G3 (P = NS) | G1: 12.5 (5.1)
| | | | | | | | | G2: 10.8 (0.4)
| | | | | | | | | G3: 14.6 (3.3
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 36 wks (Post-tx):
| | | | | | | | | G1: 12.0 (5.1)
| | | | | | | | | G2: 10.9 (4.5)
| | | | | | | | | G3: 13.4 (3.4)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Remission of BE, %:
| | | | | | | | | 36 wks (Post-tx):
| | | | | | | | | G1: 19%
| | | | | | | | | G2: 37%
| | | | | | | | | G3: 41%
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 3 mo FU:
| | | | | | | | | G1: 14%
| | | | | | | | | G2: 28%
| | | | | | | | | G3: 32%
| | | | | | | | | Diff between groups (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | CBT: Individually administered CBT using guided self-help and Overcoming Binge Eating (Fairburn 1995). 6 brief individual meetings (15 – 20 minute sessions) during 12 wk period. | ANCOVA | Score: | | Remission rates (No OBEs for past 28 days based on EDE), N (%): | BDI, mean (SD): | BDI, mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD): | Wt Loss (kg), mean (SD):
Grilo, Masheb, and Salant, 2005 | To determine whether adding Orlistat (a lipase inhibitor used for txing obesity) to CBT facilitates wt loss in obese individuals with BED | G1: Orlistat plus CBT (N = 25) | Range (35-58) | DSM IV criteria for BED; age: 35-60; BMI ≥ 30. | Meds: Orlistat (120 mg 3 times per day) or placebo for12 wks. Patients given a once-daily fat soluble multivitamin to be taken 2 hrs prior to study med at dinner. Clinical mgt of meds included brief individual meetings (10 – 15 m) held wkly during the first 4 wks and then moly. | | Good | | Post Tx: | G1: 17.1 (8.9) | Post tx: | 36.0 (4.7) | Post-tx:
Setting: | | G2: Placebo plus CBT (N = 25) | G1: 45.2 (7.4) | Exclusion: | Diet: Instructed to eat 3 meals and 2-3 snacks per day; aim for modest balanced calorie diet with goals of 1200 kcal for women and 1500 kcal for men, limit fat to less than 30% of intake, and follow Food Guide Pyramid for balanced food choices and portion sizes. | | Intent to treat: | | G1: 16 (64%) | G2: 20.6 (9.6) | G1: 10.1 (7.7) (P = NR) | G1: 36.2 (4.7) | G1: -3.5 (3.5) (P = NR)
Outpatient, Yale University Medical School, USA | | Enrollment: | G2: 47.0 (7.0) | Concurrent tx for eating, wt, or psychiatric illness; medical conditions that influence wt or eating (e.g., diabetes or thyroid problems, as determined by laboratory testing); severe current psychiatric conditions requiring diff txs (psychosis, bipolar disorder); pregnancy or lactation. | Assessments at end of 12 wks of tx and at 2 mo FU. Encouraged to continue to use CBT teachings during FU but to not take orlistat or begin new tx. | | Yes | | G2: 9 (36%) | (P = NS) | G2: 14.7 (9.0) (P = NR) | G2: 36.8 (5.1) | G2: -1.6 (2.4) (P = NR)
Enrollment period: NR | | Telephone Screened: 174 | (P = NS) | | | | Blinding: | | Diff between groups (P = 0.05) | | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR)
| | Evaluated: 61 | Age of onset, yrs, mean (SD): | | | | Double | | G1 better G2 | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = 0.02)
| | Randomized: 50 | G1: 23.5 (12.2) | | | | Adverse events: | | Diff between groups in change over time (P = NR) | | FU: | | G1 better than G2
| | Drop outs: | G2: 27.2 (14.0) | | | | General side effects were “slightly higher” in G1. Particularly, gastrointestinal events were higher for G1. | | FU: | | G1: 9.9 (8.6) (P = NR) | | FU:
| | G1: 6 | (P = NS) | | | | Drop out due to side effects: | | G1: 13 (52%); (P = NR) | | G2: 14.6 (10.9) (P = NR) | | G1: 3.4 (5.0) (P = NR)
| | G2: 5 | Sex, Female: N (%): | | | | G1: N = 2 | | G2: 13 (52%); (P = NR) | | Diff between groups (P = NR) | | G2: 1.3 (3.1) (P = NR)
| | Completed Trial, N (%): | G1: 21 (84%) | | | | G2: N = 0 | | Diff between groups (P = NS) | | Diff between groups in change over time (P = NS) | | Diff between groups (P = NR)
| | Total: 39 (78) | G2: 23 (92%) | | | | (P = NR) | | Diff between groups in change over time (P = NR) | | | | Diff between groups in change over time (P = NS)
| | G1: 19 (76%) | (P = NS) | | | | Funding: | | | | | | Percentage Wt Loss, mean (SD):
| | G2: 20 (80%) | Race/ethnicity, N (%): | | | | American Heart Association; Donaghue Medical Research Foundation | | | | | | Post-tx:
| | (P = NS) | Caucasian: | | | | | | | | | | G1: -3.3% (3.3); (P = NR)
| | | G1: 22 (88%) | | | | | | | | | | G2: -1.6% (2.4); (P = NR)
| | | G2: 22 (88%) | | | | | | | | | | Diff between groups (P = NR)
| | | African American: | | | | | | | | | | Diff between groups in change over time (P = 0.04)
| | | G1: 1 (4%) | | | | | | | | | | G1 better G2
| | | G2: 2 (8%) | | | | | | | | | | FU:
| | | Hispanic: | | | | | | | | | | G1: 3.4 (5.0) (P = NR)
| | | G1: 2 (8%) | | | | | | | | | | G2: 1.3 (3.1) (P = NR)
| | | G2: 1 (4%) | | | | | | | | | | Diff between groups (P = NR)
| | | Race/ethnicity (P = NS) | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | Attended or completed college, N (%): | | | | | | | | | | G1: 3.3 (5.0) (P = NR)
| | | G1: 20 (80%) | | | | | | | | | | G2: 1.3 (3.0) (P = NR)
| | | G2: 21 (84%) | | | | | | | | | | Diff between groups (P = NR)
| | | (P = NS) | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | DSM IV Dx, Lifetime, N (%): | | | | | | | | | | Achieved ≥ 5% Wt loss, N (%):
| | | Any Axis 1: | | | | | | | | | | Post-tx:
| | | G1: 13 (52%) | | | | | | | | | | G1: 9 (36%) (P = NR)
| | | G2: 17 (68%) | | | | | | | | | | G2: 2 (8%) (P = NR)
| | | (P = NS) | | | | | | | | | | Diff between groups (P = 0.02)
| | | Major depressive disorder: | | | | | | | | | | G1 better than G2
| | | G1: 9 (36%) | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | G2: 12 (48%) | | | | | | | | | | FU:
| | | (P = NS) | | | | | | | | | | G1: 8 (32%); (P = NR)
| | | Dysthymic disorder: | | | | | | | | | | G2: 2 (8%); (P = NR)
| | | G1: 1 (4%) | | | | | | | | | | Diff between groups (P = 0.03)
| | | G2: 4 (16%) | | | | | | | | | | G1 better than G2
| | | (P = NS) | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | Anxiety Disorders: | | | | | EDE Binge episodes (OBE)/ mo: | Binge Eating, OBEs/Mo, mean (SD):
| | | G1: 6 (24%) | | | | | G1: 16.4 (8.0) | Post Treatment:
| | | G2: 6 (24%) | | | | | G2: 13.5 (6.6) | G1: 3.2 (5.5) (P = NR)
| | | (P = NS) | | | | | (P = NS) | G2: 3.6 (5.2) (P = NR)
| | | Substance use disorders: | | | | | | Diff between groups (P = NR)
| | | G1: 4 (16%) | | | | | | Diff between groups in change over time (P = NS)
| | | G2: 1 (4%) | | | | | | FU:
| | | (P = NS) | | | | | | G1: 3.4 (6.5) (P = NR)
| | | | | | | | | G2: 2.8 (5.3) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE, dietary restraint, mean (SD): | EDE, dietary restraint, mean (SD):
| | | | | | | | G1: 2.0 (1.4) | Post Treatment:
| | | | | | | | G2: 2.1 (1.4) | G1: 2.1 (2.3) (P = NR)
| | | | | | | | (P = NS) | G2: 2.0 (1.1) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | FU:
| | | | | | | | | G1: 2.1 (1.3) (P = NR)
| | | | | | | | | G2: 2.3 (1.3) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE, eating concern, mean (SD): | EDE, eating concern, mean (SD):
| | | | | | | | G1: 2.6 (1.3) | Post Treatment:
| | | | | | | | G2: 2.7 (1.1) | G1: 0.9 (1.0) (P = NR)
| | | | | | | | (P = NS) | G2: 1.0 (1.0) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | FU:
| | | | | | | | | G1: 1.1 (1.3) (P = NR)
| | | | | | | | | G2: 1.2 (1.4) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE, wt concern, mean (SD): | EDE, wt concern, mean (SD):
| | | | | | | | G1: 3.9 (0.8) | Post Treatment:
| | | | | | | | G2: 3.7 (0.7) | G1: 2.8 (1.1) (P = NR)
| | | | | | | | (P = NS) | G2: 3.0 (0.7) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | FU:
| | | | | | | | | G1: 2.8 (1.3) (P = NR)
| | | | | | | | | G2: 2.7 (1.1) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE, shape concern, mean (SD): | EDE, shape concern, mean (SD):
| | | | | | | | G1: 4.3 (0.8) | Post Treatment:
| | | | | | | | G2: 4.4 (0.8) | G1: 2.8 (1.4) (P = NR)
| | | | | | | | (P = NS) | G2: 3.3 (1.1) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | FU:
| | | | | | | | | G1: 2.9 (1.6) (P = NR)
| | | | | | | | | G2: 3.0 (1.4) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE interview global score, mean (SD): | EDE interview global score, mean (SD):
| | | | | | | | G1: 3.2 (0.9) | Post Treatment:
| | | | | | | | G2: 3.2 (0.7) | G1: 2.1 (1.0) (P = NR)
| | | | | | | | (P = NS) | G2: 2.4 (0.7) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | FU:
| | | | | | | | | G1: 2.2 (1.1) (P = NR)
| | | | | | | | | G2: 2.3 (1.0) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Pharmacological Treatment: Fluoxetine (60 mg/day) started immediately and without taper at end of tx. Clinical management involved brief individual meetings (10 – 15 min) held wkly during first 4 wks and bi-wkly thereafter. Meetings focused solely on medical regimen. | Logistic regression analyses compared remission rates based on self-monitoring across the tx while controlling for the frequency of OBEs for the mo prior to beginning tx as determined at baseline. | Score: | EDE Binge days (OBE)/mo, mean (SD): | | BDI, mean (SD): | BDI, mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD):
Grilo, Masheb and Wilson, 2005 | To test the efficacy of CBT and fluoxetine alone and in combination for BED. | G1: Placebo (N = 27) | Range (21-59) | DSM IV criteria for BED; Age: 18-60; 100%-200% of ideal wt for hgt. | CBT: wkly individual 60-minutes sessions for 16 wks and followed Fairburn’s manual for BN. | ANCOVA and repeated measures ANOVAs used for secondary analyses. | Good | G1: 13.5 (7.4) | | G1: 18.7 (9.7) | G1: 11.7 (10.3) (P = NR) | G1: 35.7 (7.2) | G1: 35.7 (7.5) (P = NR)
Setting: | | G2: fluoxetine (N = 27) | G1: 43.6 (8.5) | Exclusion: | Patients self monitored overeating behaviors including binge eating. Tx: 16 wks | | Intent to treat: | G2: 16.5 (7.6) | | G2: 16.9 (8.4) | G2: 11.8 (9.8)) (P = NR) | G2: 38.9 (9.5) | G2: 38.1 (9.6) (P = NR)
Outpatient,Yale University; New Haven, CT, USA | | G3: CBT + placebo (N = 28) | G2: 44.3 (9.5) | Any concurrent tx for eating, wt, or psychiatric problems; medical conditions (diabetes, thyroid problems, hypoglycemia) that influence wt/eating; severe psychiatric conditions requiring diff txs (psychosis, bipolar disorder); and pregnancy or lactation. | | | Yes | G3: 17.4 (7.5) | | G3: 16.5 (8.4) | G3: 6.5 (6.8) (P = NR) | G3: 35.0 (6.2) | G3: 34.2 (5.8) (P = NR)
Enrollment period: NR | | G4: CBT + fluoxetine (N = 26) | G3: 43.6 (8.5) | | | | Blinding: | G4: 16.5 (7.2) | | G4: 20.2 (12.1) | G4: 9.2 (7.3) (P = NR) | G4: 35.7 (8.3) | G4: 34.9 (7.9) (P = NR)
| | Enrollment: | G4: 44.7 (8.1) | | | | Double | (P = NS) | | (P = NS) | Diff between groups: | (P = NS) | Diff between groups
| | Telephone Screened: 410 | (P = NS) | | | | Adverse events: | | | | G1 vs G2 (P = NS) | | (P = NR)
| | Personal Interview: 200 | Sex: | | | | NR | | | | G3 vs G4 (P = NS) | | Diff between groups in change over time
| | Met criteria and were randomized: 108 | Female, N (%): | | | | Funding: | | | | G3 vs G1 (P = 0.04) | | (P = NS)
| | Completed, N (%): | G1: 23 (85.2) | | | | National Institutes of Healthy. Eli Lily and Co provided fluoxetine and matching Placebo Pills | | | | G3 better than G1
| | G1: 23 (85%) | G2: 19 (70.4) | | | | | | | | G3 vs G2 (P = 0.01)
| | G2: 21 (78%) | G3: 22 (78.6) | | | | | | | | G3 better than G2
| | G3: 22 (79%) | G4: 20 (76.9) | | | | | | | | G4 vs G1 (P = NS)
| | G4: 20 (77%) | (P = NS) | | | | | | | | G4 vs G2 (P = 0.04)
| | (P = NS) | Race/ethnicity, N (%): | | | | | | | | G4 better than G2
| | | Caucasian: G1: 20 (74.1) | | | | | | | | Diff between groups in change over time (P = NR)
| | | G2: 27 (100) | | | | | EDE Binge episodes (OBE)/mo, mean (SD): | Binge episodes/mo (EDE-Q), mean (SD):
| | | G3: 26 (92.9) | | | | | G1: 16.3 (11.9) | G1: 7.2 (9.2) (P = NR)
| | | G4: 23 (88.5) | | | | | G2: 20.0 (11.6) | G2: 10.3 (11.1) (P = NR)
| | | African-American: | | | | | G3: 22.8 (14.7) | G3: 1.8 (3.9) (P = NR)
| | | G1: 5 (18.5) | | | | | G4: 22.7 (13.7) | G4: 4.7 (6.9) (P = NR)
| | | G2: 0 (0) | | | | | (P = NS) | Diff between groups:
| | | G3: 2 (7.1) | | | | | | G1 vs G2(P = NS)
| | | G4: 2 (7.7) | | | | | | G3 vs G4 (P = NS)
| | | Hispanic-American: | | | | | | G3 vs G1 (P = 0.002)
| | | G1: 2 (7.4) | | | | | | G3 better than G1
| | | G2: 0 (0) | | | | | | G3 vs G2 (P = 0.000)
| | | G3: 0 (0) | | | | | | G3 better than G2
| | | G4: 1 (3.8) | | | | | | G4 vs G1 (P = 0.02)
| | | (P = NS) | | | | | | G4 better than G1
| | | Education, N (%): Attended/Finished College: | | | | | | G4 vs G2 (P = 0.001)
| | | Total Sample: 95 (87%) | | | | | | G4 better than G2
| | | College: | | | | | | Diff between groups in change over time (P = NR)
| | | G1: 13 (48.1) | | | | | EDE Q Binge episodes/mo, mean (SD): | Binge episodes/mo (daily self-monitoring), mean (SD):
| | | G2: 14 (51.9) | | | | | G1: 13.2 (9.3) | G1: 7.4 (10.2) (P = NR)
| | | G3: 14 (50.0) | | | | | G2: 17.9 (12.2) | G2: 11.0 (11.2) (P = NR)
| | | G4: 11 (42.3) | | | | | G3: 16.6 (8.9) | G3: 2.6 (5.8) (P = NR)
| | | Some College: | | | | | G4: 15.2 (7.7) | G4: 4.2 (6.9) (P = NR)
| | | G1: 12 (44.4) | | | | | (P = NS) | (P = NR)
| | | G2: 11 (40.7) | | | | | | Diff between groups:
| | | G3: 9 (32.1) G4: 11 (42.3) | | | | | | G1 vs G2 (P = NS)
| | | HS: | | | | | | G3 vs G4 (P = NS)
| | | G1: 2 (7.4) | | | | | | G3 vs G1 (P = 0.004)
| | | G2: 2 (7.4) | | | | | | G3 better than G1
| | | G3: 5 (17.9) | | | | | | G3 vs G2 (P = 0.04)
| | | G4: 4 (15.4) | | | | | | G3 better than G2
| | | (P = NS) | | | | | | G4 vs G1 (P = 0.05)
| | | DSM IV Co-morbidity Lifetime, N (%): | | | | | | G4 better than G1
| | | Any Axis I Disorder: | | | | | | G4 vs G2 (P = 0.001)
| | | G1: 17 (63.0) | | | | | | G4 better than G2
| | | G2: 20 (74.1) | | | | | | Diff between groups in change over time (P = NR)
| | | G3: 21 (75.0) | | | | | EDE-Q Dietary Restraint, mean (SD): | EDE-Q Dietary Restraint, mean (SD):
| | | G4: 21 (80.8) | | | | | G1: 2.2 (1.5) | G1: 1.8 (1.5) (P = NR)
| | | (P = NS) | | | | | G2: 2.4 (1.7) | G2: 2.4 (1.6) (P = NR)
| | | Major Depressive Disorder: | | | | | G3: 2.6 (1.5) | G3: 1.4 (1.0) (P = NR)
| | | G1: 12 (44.4) | | | | | G4: 2.5 (1.4) | G4: 1.6 (1.4) (P = NR)
| | | G2: 11 (40.7) | | | | | (P = NS) | Diff between groups:
| | | G3: 17 (60.7) | | | | | | G1 vs G2 (P = NS)
| | | G4: 14 (50.0) | | | | | | G3 vs G4 (P = NS)
| | | (P = NS) | | | | | | G3 vs G1 (P = NS)
| | | Anxiety Disorders: | | | | | | G3 vs G2 (P = 0.002)
| | | G1: 10 (37.0) | | | | | | G3 better than G2
| | | G2: 9 (33.3) | | | | | | G4 vs G1 (P = NS)
| | | G3: 13 (46.4) | | | | | | G4 vs G2 (P = 0.01)
| | | G4: 8 (30.8) | | | | | | G4 better than G2
| | | (P = NS) | | | | | | Diff between groups in change over time (P = NR)
| | | Alcohol use disorders: | | | | | EDE-Q Eating Concern, mean (SD): | EDE-Q Eating Concern, mean (SD):
| | | G1: 7 (25.9) | | | | | G1: 3.4 (1.4) | G1: 2.1 (1.5) (P = NR)
| | | G2: 4 (14.8) | | | | | G2: 4.0 (1.2) | G2: 2.8 (1.8) (P = NR)
| | | G3: 6 (21.4) | | | | | G3: 3.6 (1.2) | G3: 1.3 (0.7) (P = NR)
| | | G4: 9 (34.6) | | | | | G4: 3.9 (1.2) | G4: 1.5 (1.3) (P = NR)
| | | (P = NS) | | | | | (P = NS) | Diff between groups:
| | | Drug use disorders: | | | | | | G1 vs G2 (P = NS)
| | | G1: 5 (18.5) | | | | | | G3 vs G4 (P = NS)
| | | G2: 4 (14.8) | | | | | | G3 vs G1 (P = 0.01)
| | | G3: 6 (21.4) | | | | | | G3 better than G1
| | | G4: 4 (15.4) | | | | | | G3 vs G2 (P = 0.01)
| | | (P = NS) | | | | | | G3 better than G2
| | | Any Axis II personality disorder: | | | | | | G4 vs G1 (P = 0.007)
| | | G1: 12 (44.4) | | | | | | G4 better than G1
| | | G2: 7 (25.9) | | | | | | G4 vs G2 (P = 0.008)
| | | G3: 7 (25.0) | | | | | | G4 better than G2
| | | G4: 8 (30.8) | | | | | | Diff between groups in change over time (P = NR)
| | | (P = NS) | | | | | Wt Concern (EDE-Q), mean (SD): G1: | Wt Concern (EDE-Q), mean (SD):
| | | Age Onset BED, mean (SD): | | | | | 3.9 (1.5) | G1: 3.0 (1.5) (P = NR)
| | | G1: 23.8 (19.0) | | | | | G2: 4.1 (0.9) | G2: 3.3 (1.3) (P = NR)
| | | G2: 24.5 (11.9) | | | | | G3: 4.0 (0.8) | G3: 2.6 (1.0) (P = NR)
| | | G3: 25.9 (18.1) | | | | | G4: 4.3 (0.9) | G4: 2.4 (1.5) (P = NR)
| | | G4: 22.4 (13.0) | | | | | (P = NS) | Diff between groups:
| | | (P = NS) | | | | | | G1 vs G2 (P = NS)
| | | | | | | | | G3 vs G4 (P = NS)
| | | | | | | | | G3 vs G1 (P = NS)
| | | | | | | | | G3 vs G2(P = 0.04)
| | | | | | | | | G3 better than G2
| | | | | | | | | G4 vs G1 (P = 0.01)
| | | | | | | | | G4 better than g1
| | | | | | | | | G4 vs G2 (P = 0.001)
| | | | | | | | | G4 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE-Q Shape Concern, mean (SD): | EDE-Q Shape Concern, mean (SD):
| | | | | | | | G1: 4.5 (1.4) | G1: 3.6 (1.8) (P = NR)
| | | | | | | | G2: 5.0 (0.8) | G2: 3.9 (1.7) (P = NR)
| | | | | | | | G3: 5.0 (0.8) | G3: 3.2 (1.4) (P = NR)
| | | | | | | | G4: 5.1 (0.7) | G4: 3.1 (1.8) (P = NR)
| | | | | | | | (P = NS) | Diff between groups:
| | | | | | | | | G1 vs G2 (P = NS)
| | | | | | | | | G3 vs G4 (P = NS)
| | | | | | | | | G3 vs G1 (P = 0.02)
| | | | | | | | | G3 better than G1
| | | | | | | | | G3 vs G2 (P = 0.04)
| | | | | | | | | G3 better than G2
| | | | | | | | | G4 vs G1 (P = 0.003)
| | | | | | | | | G4 better than G1
| | | | | | | | | G4 vs G2 (P = 0.007)
| | | | | | | | | G4 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE-Q Global Score, mean (SD): | EDE-Q Global Score, mean (SD):
| | | | | | | | G1: 3.5 (1.5) | G1: 2.6 (1.6) (P = NR)
| | | | | | | | G2: 3.9 (1.2) | G2: 3.1 (1.6) (P = NR)
| | | | | | | | G3: 3.8 (1.1) | G3: 2.1 (1.0) (P = NR)
| | | | | | | | G4: 4.0 (1.1) | G4: 2.2 (1.5) (P = NR)
| | | | | | | | (P = NS) | Diff between groups:
| | | | | | | | | G1 vs G2 (P = NS)
| | | | | | | | | G3 vs G4 (P = NS)
| | | | | | | | | G3 vs G1 (P = 0.007)
| | | | | | | | | G3 better than G1
| | | | | | | | | G3 vs G2 (P = 0.004)
| | | | | | | | | G3 better than G2
| | | | | | | | | G4 vs G1 (P = 0.002)
| | | | | | | | | G4 better than G1
| | | | | | | | | G4 vs G2 (P = 0.001)
| | | | | | | | | G4 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | TFEQ Hunger, mean (SD): | TFEQ Hunger, mean (SD):
| | | | | | | | G1: 9.6 (3.9) | G1: 8.4 (4.3) (P = NR)
| | | | | | | | G2: 10.0 (3.3) | G2: 8.9 (4.6) (P = NR)
| | | | | | | | G3: 9.7 (3.2) | G3: 6.7 (3.3) (P = NR)
| | | | | | | | G4: 10.0 (3.1) | G4: 5.7 (4.0) (P = NR)
| | | | | | | | (P = NS) | Diff between groups:
| | | | | | | | | G1 vs G2 (P = NS)
| | | | | | | | | G3 vs G4 (P = NS)
| | | | | | | | | G3 vs G1 (P = NS)
| | | | | | | | | G3 vs G2 (P = NS)
| | | | | | | | | G4 vs G1 (P = 0.008)
| | | | | | | | | G4 better than G1
| | | | | | | | | G4 vs G2 (P = 0.004)
| | | | | | | | | G4 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | TFEQ Cognitive Restraint, mean (SD): | TFEQ Cognitive Restraint, mean (SD):
| | | | | | | | G1: 8.1 (3.63) | G1: 9.9 (5.0) (P = NR)
| | | | | | | | G2: 8.6 (4.0) | G2: 9.9 (4.7) (P = NR)
| | | | | | | | G3: 7.8 (3.7) | G3: 10.1 (3.1) (P = NR)
| | | | | | | | G4: 8.7 (4.5) | G4: 10.0 (4.1) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | TFEQ Disinhibition, mean (SD): | TFEQ Disinhibition, mean (SD):
| | | | | | | | G1: 13.9 (1.9) | G1: 12.1 (4.3) (P = NR)
| | | | | | | | G2: 14.0 (1.3) | G2: 12.2 (3.6) (P = NR)
| | | | | | | | G3: 14.2 (1.6) | G3: 9.3 (3.8) (P = NR)
| | | | | | | | G4: 14.0 (1.7) | G4: 8.3 (4.8) (P = NR)
| | | | | | | | (P = NS) | Diff between groups:
| | | | | | | | | G1 vs G2 (P = NS)
| | | | | | | | | G3 vs G4 (P = NS)
| | | | | | | | | G3 vs G1 (P = 0.001)
| | | | | | | | | G3 better than G1
| | | | | | | | | G3 vs G2 (P = 0.002)
| | | | | | | | | G3 better than G2
| | | | | | | | | G4 vs G1 (P = 0.000)
| | | | | | | | | G4 better than G1
| | | | | | | | | G4 vs G2 (P = 0.001)
| | | | | | | | | G4 better than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | BSQ, Body Dissatisfaction, mean (SD) | BSQ, Body Dissatisfaction, mean (SD):
| | | | | | | | G1: 135.4 (35.2) | G1: 123.6 (41.0) (P = NR)
| | | | | | | | G2: 136.3 (26.0) | G2: 117.5 (41.5) (P = NR)
| | | | | | | | G3: 133.5 (24.3) | G3: 100.9 (23.5) (P = NR)
| | | | | | | | G4: 139.1 (28.8) | G4: 106.0 (40.2) (P = NR)
| | | | | | | | (P = NS) | Diff between groups:
| | | | | | | | | G1 vs G2 (P = NS)
| | | | | | | | | G3 vs G4 (P = NS)
| | | | | | | | | G3 vs G1 (P = NS)
| | | | | | | | | G3 vs G2 (P = 0.03)
| | | | | | | | | G3 better than G2
| | | | | | | | | G4 vs G1 (P = 0.05)
| | | | | | | | | G4 better than G1
| | | | | | | | | G4 vs G2 (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Remission rates (Per EDE), %:
| | | | | | | | | G1: 26%
| | | | | | | | | G2: 22%
| | | | | | | | | G3: 61%
| | | | | | | | | G4: 50%
| | | | | | | | | Diff between groups (P = 0.007)
| | | | | | | | | G1 vs G2 (P = NS)
| | | | | | | | | G3 vs G4 (P = NS)
| | | | | | | | | G4 vs G1 (P = 0.05) G4 better than G1
| | | | | | | | | G4 vs G2 (P = 0.03) G4 better than G2
| | | | | | | | | G3 vs G1 (P = 0.008) G3 better than G1
| | | | | | | | | G3 vs G2 (P = 0.004) G3 better than G2
| | | | | | | | | Remission rates (Per EDE-Q):
| | | | | | | | | G1: Data in figure
| | | | | | | | | G2: Data in figure
| | | | | | | | | G3: Data in figure
| | | | | | | | | G4: Data in figure
| | | | | | | | | Diff between groups (P = 0.003)
| | | | | | | | | G1 vs G2 (P = NS)
| | | | | | | | | G3 vs G4 (P = NS)
| | | | | | | | | G4 vs G1 (P = 0.02) G4 better than G1
| | | | | | | | | G4 vs G2 (P = 0.003) G4 better than G2
| | | | | | | | | G3 vs G1 (P = 0.03) G3 better than G1
| | | | | | | | | G3 vs G2 (P = 0.005) G3 better than G2
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | G1: 22 individual sessions of 50 min each for 24 wks. | Chi Square, ANOVA, Wilcoxin, Mann-Whitney U. No adjustment for multiple comparisons | Score: | EDE total score, median: | EDE total score, median: | BDI, median: | BDI, median: | | BMI:
Ricca et al., 2001 | Compare the efficacy and tolerability of fluoxetine, fluvoxamine, and CBT, individually and combined with each other, after 6 mos of acute tx and one yr FU among patients with BED. | G1: CBT (N = 20) | 25.9 (6.8) | BED dx per DSM IV; age: 18-45; absence of diabetes mellitus, thyroid disorders, or any other disease interfering with eating behavior; absence of any contraindication to tx; absence of pregnancy or lactation. | G2: 20 mg/day for first wk; 40 mg/day for second wk; 60 mg/day for following 20 wks in a single dose. CBT as in G1 | Data collected at end of tx (6 mos) and 1 yr FU | Poor | G1: 3.8 | Post-tx: | G1: 22 | Post tx: | | Post-tx:
Setting: | | G2: CBT + Fluoxetine (N = 22) | G1: 26.3 (6.7) | Exclusion: | G3: 100 mg/day for the first wk; 100 mg bid for the second wk; 100 mg tid for the next 20 wks. CBT as in G1 | | Intent to treat: | G2: 3.8 | G1: 3.4 (P < 0.01) | G2: 16.5 | G1: 14 (P < 0.01) | | G1 - G5: Data presented in figure only
Outpatient clinic for ED of the University of Florence and the Casa di Cura (villa dei pini), Florence, Italy | | G3: CBT + Fluvoxamine (N = 23) | G2: 25.2 (6.3) | See above | G4: 20 mg/day for first wk; 40 mg/day for second wk; 60 mg/day for following 20 wks in a single dose. Visits: once per mo. Therapy interrupted if serious adverse events. | | Yes | G3: 4.0 | G2: 2.7 (P < 0.01) | G3: 22 | G2: 10.5 (P < 0.01) | | G1: change (P < 0.01)
Enrollment period: | | G4: Fluoxetine (N = 21) | G3: 25.1 (6.9) | | G5: 100 mg/day for the first wk; 100 mg bid for the second wk; 100 mg tid for the next 20 wks. Visits: once per mo. Therapy interrupted if serious adverse events. | | Blinding: | G4: 3.4 | G3: 2.7 (P < 0.01) | G4: 20 | G3: 10 (P < 0.01) | | G2: change (P < 0.01)
January 1 – July 31, 1998 | | G5: Fluvoxamine (N = 22) | G4: 25.1 (6.1) | | After the 24^th^ wk, therapy ended. Drugs progressively decreased up to discontinuation over a period of 1 mo. No further tx or FU for 1 yr. | | No | G5: 3.8 | G4: 3.8 (P = NS) | G5: 21 | G4: 15 (P < 0.01) | | G3: change (P < 0.01)
| | Enrollment: | G5: 26.1 (5.9) | | | | Adverse events: | (P = NR) | G5: 3.8; (P = NS) | (P = NR) | G5: 14 (P < 0.01) | | G4: change (P = NS)
| | - 118 referred; - 7 did not meet criteria, 3 refused; - 108 were randomized. | (P = NS) | | | | G2: 6 (27.2%) (nausea: 4, insomnia: 3; anorgasmia: 1; vomiting; reduction in drug dose: 2 | | Diff between groups (P = NR) | | Diff between groups (P = NR) | | G5: change (P = NS)
| | Drop out, N (%): | Sex, N: | | | | G3: 6 (nausea: 5, hypersomnia: 2; diarrhea: 1; required reduction in drug dose: 3 | | Diff between groups in change over time (P < 0.05) G3 better than G1 or G2 | | Diff between groups in change over time (P = NS) | | Diff between groups (P = NR)
| | G1: 3 | Female: 64; Male: 44 | | | | G4: 7 (nausea: 4; headache: 3; vomiting: 2; insomnia: 1); required reduction in drug dose: 4 | | 1 yr FU: | | 1 yr FU: | | Diff between G1, G2, G3 in change over time (P = NS)
| | G2: 6 (27.2) | G1: F: 13; M: 7 | | | | G5: 7 (nausea: 5; hypersomnia: 3; headache: 2; vomiting: 2); required a reduction in drug dose: 3 | | G1: 3.3 (P = NS) | | G1: 14 (P = NS) | | 1 yr FU:
| | G3: 5 (21.7) | G2: F: 13; M: 9 | | | | Funding: | | G2: 2.7 (P = NS) | | G2: 10.5 (P = NS) | | G1 - G5: Data presented in figure only
| | G4: 5 (23.8) | G3: F: 13; M: 10 | | | | NR | | G3: 2.6 (P = NS) | | G3: 10 (P = NS) | | G1: change (P < 0.01)
| | G5: 6 (27.2) | G4: F: 12; M: 9 | | | | | | G4: 3.9 (P = NS) | | G4: 16 (P = NS) | | G2: change (P < 0.01)
| | (P = NS) | G5: F:13; M:9 | | | | | | G5: 3.8 (P = NS) | | G5: 14 (P = NS) | | G3: change (P < 0.01)
| | Subjects allocated to tx by day of the wk of appointment. Drug tx is open label | (P = NS) | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR) | | G4: change (P = NS)
| | | Race/ethnicity: | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR) | | G5: change (P = NS)
| | | NR | | | | | | | | | | Diff between groups (P = NR)
| | | BMI, mean (SD): | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | G1: 32.0 (6.0) | | | | | EDE Restraint, median: | EDE Restraint, median: | STAI-State, median: | STAI-State, median:
| | | G2: 31.7 (5.6) | | | | | G1: 3.8 | Post-tx:
| | | G3: 32.5 (6.1) | | | | | G2: 2.6 | G1: 2.9 (P < 0.01)
| | | G4: 32.1 (3.8) | | | | | G3: 3.3 | G2: 2.7 (P = NS) | G1: 46 | Post tx:
| | | G5: 32.7 (4.1) | | | | | G4: 3.8 | G3: 2.1 (P < 0.01) | G2: 47.5 | G1: 37 (P < 0.01)
| | | (P = NS) | | | | | G5: 3.5 | G4: 3.9 (P = NS) | G3: 52 | G2: 45 (P = NS)
| | | Duration of BED, yrs, mean (SD): | | | | | (P = NR) | G5: 3.4 (P = NS) | G4: 46.2 | G3: 32 (P < 0.01)
| | | G1: 6.4 (6.0) | | | | | | Diff between groups (P = NR) | G5: 48.2 | G4: 44.8 (P = NS)
| | | G2: 4.9 (5.1) | | | | | | Diff between groups in change over time (P < 0.01) G3 better than G1 or G2 | (P = NR) | G5: 34.1 (P < 0.01)
| | | G3: 4.8 (4.4) | | | | | | 1 yr FU: | | Diff between groups (P = NR)
| | | G4: 5.1 (4.7) | | | | | | G1: 2.8 (P = NS) | | Diff between groups in change over time (P < 0.01)
| | | G5: 5.3 (4.8) | | | | | | G2: 2.7 (P = NS) | | G3 better than G1
| | | (P = NS) | | | | | | G3: 2.1 (P = NS) | | 1 yr FU:
| | | Age of Onset, mean (SD): | | | | | | G4: 3.9 (P = NS) | | G1: 40 (P = NS)
| | | G1: 19.9 (2.3) | | | | | | G5: 3.4 (P = NS) | | G2: 48 (P = NS)
| | | G2: 24.4 (3.2) | | | | | | Diff between groups (P = NR) | | G3: 32 (P = NS)
| | | G3: 20.5 (3.6) | | | | | | Diff between groups in change over time (P = NR) | | G4: 50.5 (P < 0.01)
| | | G4: 21.2 (3.1) | | | | | | | | G5: 36.1 (P = NS)
| | | G5: 22.1 (3.6) | | | | | | | | Diff between groups (P = NR)
| | | (P = NS) | | | | | | | | Diff between groups in change over time (P = NR)
| | | Comorbidity per SCID for DSM III-R, N (%): | | | | | EDE Eating concern, median: | EDE Eating concern, median: | STAI-Trait, median: | STAI-Trait, median:
| | | Total people with comorbid dx: 15 | | | | | G1: 3.6 | Post-tx: | G1: 48 | Post tx:
| | | Major depression: 7 (6.4) | | | | | G2: 3.6 | G1: 3.3 (P < 0.01) | G2: 48 | G1: 44.5 (P < 0.01)
| | | Dysthymia: 6 (5.5) | | | | | G3: 4.4 | G2: 2.8 (P < 0.01) | G3: 52 | G2: 46 (P = NS)
| | | Adaptation disorder with depressed mood: 4 (3.6) | | | | | G4: 4.0 | G3: 2.8 (P < 0.01) | G4: 47.5 | G3: 36 (P < 0.01)
| | | OCD: 2 (1.8) | | | | | G5: 3.8 | G4: 3.9 (P = NS) | G5: 49.6 | G4: 46.8 (P = NS)
| | | Panic Disorder: 2 (1.8) | | | | | (P = NR) | G5: 3.7 (P = NS) | (P = NR) | G5: 35 (P < 0.01)
| | | | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.01) G2 and G3 better than G1 | | Diff between groups in change over time
| | | | | | | | | 1 yr FU: | | G3 better than G1(P < 0.01)
| | | | | | | | | G1: 3.3 (P = NS) | | G5 better than G1 (P < 0.01)
| | | | | | | | | G2: 2.8 (P = NS) | | 1 yr FU:
| | | | | | | | | G3: 2.1 (P = NS) | | G1: 44 (P = NS)
| | | | | | | | | G4: 4.0 (P = NS) | | G2: 48 (P = NS)
| | | | | | | | | G5: 3.7 (P = NS) | | G3: 36 (P = NS)
| | | | | | | | | Diff between groups (P = NR) | | G4: 47.1 (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR) | | G5: 34.9 (P = NS)
| | | | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE Wt Concern, median: | EDE Wt Concern, median:
| | | | | | | | G1: 4.4 | Post-tx:
| | | | | | | | G2: 4.3 | G1: 3.7 (P < 0.01)
| | | | | | | | G3: 4.2 | G2: 2.9 (P < 0.01)
| | | | | | | | G4: 4.2 | G3: 3.2 (P < 0.01)
| | | | | | | | G5: 4.3 | G4: 4.1 (P = NS)
| | | | | | | | (P = NR) | G5: 4.3 (P = NS)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 1 yr FU:
| | | | | | | | | G1: 3.6 (P = NS)
| | | | | | | | | G2: 2.9 (P = NS)
| | | | | | | | | G3: 3.0 (P = NS)
| | | | | | | | | G4: 4.0 (P = NS)
| | | | | | | | | G5: 4.2 (P = NS)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | EDE Shape Concern, median: | EDE Shape Concern, median:
| | | | | | | | G1: 3.3 | Post-tx:
| | | | | | | | G2: 3.2 | G1: 3.2 (P < 0.01)
| | | | | | | | G3: 3.7 | G2: 2.8 (P < 0.01)
| | | | | | | | G4: 3.6 | G3: 2.9 (P < 0.01)
| | | | | | | | G5: 3.5 | G4: 3.7 (P = NS)
| | | | | | | | (P = NR) | G5: 3.6 (P = NS)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 1 yr FU:
| | | | | | | | | G1: 3.1 (P = NS)
| | | | | | | | | G2: 2.2 (P = NS)
| | | | | | | | | G3: 3.1 (P = NS)
| | | | | | | | | G4: 3.8 (P = NS)
| | | | | | | | | G5: 3.6 (P = NS)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Binge eating episodes /mo, mean (SD): | Binge eating episodes /mo, mean (SD):
| | | | | | | | G1: 18 (2.3) | Post-tx:
| | | | | | | | G2: 17 (3.1) | G1: 8 (3.9) (P < 0.001)
| | | | | | | | G3: 18 (3.5) | G2: 6 (4.6) (P < 0.001)
| | | | | | | | G4: 20 (4.3) | G3: 8 (3.2) (P < 0.001)
| | | | | | | | G5: 20 (5.8) | G4: 19 (3.5) (P = NS)
| | | | | | | | (P = NR) | G5: 18 (2.4) (P = NS)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 1 yr FU:
| | | | | | | | | G1: 8 (5.1) (P = NS)
| | | | | | | | | G2: 7 (3.4) (P = NS)
| | | | | | | | | G3: 8 (2.4) (P = NS)
| | | | | | | | | G4: 21 (3.1) (P = NS)
| | | | | | | | | G5: 18 (1.7) (P = NS)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)

Evidence Table 12. Behavioral intervention trials for binge eating disorder

Study Description | Objective | Design | Patient Characteristics | Inclusion/Exclusion Criteria | Treatment | Statistical Methods | Quality | Eating Related Measures | | Psychological/Psychiatric Measures | | Biomarkers
| | | | | | | | Baseline | Outcomes | Baseline | Outcomes | Baseline | Outcomes
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Following clinical interview assessments, subjects randomized at a ratio of 4:1 to either a 12-wk CBT program or waitlist control. CBT: 12 90 minutes sessions wkly, based on manual developed by Telch, plus walking and nutritional ed. Subjects who met 3 criteria for successful response to CBT (stabilization or wt loss for at least the last 4 wks of tx; initiating a min aerobic exercise program such as walking for 30 m, 3 times per wk; and abstinence from binge eating for at least the last 2 wks of tx) were assigned to a 12-wk behavioral wt loss program. Those who did not meet the criteria for successful response after 12 wks of CBT were assigned to an additional 12 wks of IPT. IPT: group format, 90 minutes each using Wilfley (1993) design. | Repeated measure MANOVAs to assess between group diffs on primary and secondary outcome variables; signal detection methods to explore predictors of tx response. | Score: | Binge days/wk, mean (SD): | Binge days/wk, mean (SD): | BDI, mean (SD): | BDI, mean (SD): | Wt, kg, mean (SD): | Wt, kg, mean (SD):
Agras et al., 1995 | To assess the efficacy of a 12-wk CBT program for the tx of BED. Another primary goal is to evaluate whether the addition of 12 wks of IPT would improve primary BED outcomes among tx non-responders. | G1: CBT (N = 39) | Range: 24–65 | Met proposed criteria for BED (Walsh, 1992) | | | Poor | G1: 4.4 (1.8) | Wk 12 (end of tx) | G1: 14.6 (9.7) | Wk 12 (end of tx) | G1: 108 (26.7) | Wk 12 (end of tx):
Setting: | | G2: Assessment only waitlist control (N = 11) | Total sample: | Exclusion: | | | Intent to treat: | G2: 3.7 (1.2) | G1: 0.7 (1.0) (P = NR) | G2: 11.2 (6.8) | G1: 11.5 (8.7) (P = NR) | G2: 106.1 (20.3) | G1: 109.4 (27.3) (P = NR)
Single center; outpatient: location: Stanford University School of Medicine Behavioral Medicine Program, Stanford, CA, USA | | Enrollment: | 47.6 (10.1) | Current involvement in a wt loss program; currently taking anti-depressant meds or any med that could impact wt; current drug or alcohol abuse; current major psychiatric illness such as psychosis; hx of purging within the last 6 mos; BMI < 27 (i.e., not requiring tx for overwt) | | | For some analyses as a comparison. Authors reported that comparing ITT vs. non-ITT analyses revealed no Diffs, so non-ITT results reported. | (P = NS) | G2: 3.4 (2.0) (P = NR) | (P = NS) | G2: 11.9 (6.6) (P = NR) | (P = NS) | G2: 109.8 (23.1) (P = NR)
Enrollment period: | | - 262 potential subjects either referred to study or recruited via ads were phone screened; - 89 invited for in-person diagnostic interview; - 64 eligible for enrollment (14 did not complete baseline assessment); - 50 enrolled and randomized; - 42 completers at 24 wks (G1: N = 31; G2: N = 11) (P = NR) | G1: NR | | | | Blinding: | G1A: 4.2 (1.9) | Diff between groups (P = NR) | | Diff between groups (P = NS) | | Diff between groups (P = NS)
NR | | | G2: NR | | | | NA | G1B: 4.5 (1.7) | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | (P = NS) | | | | Adverse events: | (P = NS) | Wk 24: | | Wk 24: | | Wk 24:
| | | Sex: | | | | NR | | G1: 1.0 (1.4) (P = NR) | | G1: 10.5 (8.2) (P = NR) | | G1: 107.4 (28) (P = NR)
| | | Female N (%): | | | | Funding: | | G2: 2.9 (2.0) (P = NR) | | G2: 11.0 (8.3) (P = NR) | | G2: 110.2 (22.8) (P = NR)
| | | 43 (86%) | | | | NIH | | Diff between groups (P = 0.0001) | | Diff between groups (P = NS) | | Diff between groups (P = 0.02)
| | | Race/ethnicity: | | | | | | G1 better than G2 | | Diff between groups in change over time (P = NR) | | G1 less than G2
| | | NR | | | | | | Diff between groups in change over time (P = NR) | | | | Diff between groups in change from wk 12 (P = NR)
| | | Age of overwt onset, yrs, mean (SD): | | | | | BES, mean (SD): | BES, mean (SD) | SCL-90, global, mean (SD): | SCL-90, global, mean (SD):
| | | 18.9 (12.8) | | | | | G1: 29.4 (6.7) | Wk 12 (end of tx): | G1: 0.9 (0.7) | Wk 12 (end of tx)
| | | Mean age of binge eating onset, yrs, mean (SD): | | | | | G2: 25.2 (7.9) | G1: 18.1 (8.0) (P = NR) | G2: 0.8 (0.5) | G1: 0.8 (0.5) (P = NR)
| | | 21.1 (12.0) | | | | | (P > 0.01) | G2: 23.8 (6.6) (P = NR) | (P = NS) | G2: 0.8 (0.6) (P = NR)
| | | BMI, kg/m ^ 2 ^ , mean (SD): | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | Total sample: 37.1 (7.3) | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change from baseline (P = NR)
| | | G1: NR | | | | | | Wk 24: | | Wk 24:
| | | G2: NR | | | | | | G1: 17.7 (7.1) (P = NS) | | SCL-90, global mean (SD):
| | | (P = NR) | | | | | | G2: 24.9 (10.4) (P = NS) | | G1: 0.6 (0.4) (P = NR)
| | | | | | | | | Diff between groups (P = 0.0001) | | G2: 0.7 (0.7) (P = NR)
| | | | | | | | | G1 better than G2 | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | TFEQ, mean (SD): | TFEQ, Disinhibition, mean (SD):
| | | | | | | | Disinhibition: | Wk 12 (end of tx)
| | | | | | | | G1: 14.1 (1.6) | G1: 12.1 (2.6) (P = NR)
| | | | | | | | G2: 13.6 (1.6) | G2: 13.6 (1.7) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Wk 24:
| | | | | | | | | G1: 10.9 (2.9) (P = NR)
| | | | | | | | | G2: 13.5 (1.1) (P = NR)
| | | | | | | | | Diff between groups (P = 0.004)
| | | | | | | | | G1 lower than G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Hunger: | Wk 12 (end of tx)
| | | | | | | | G1: 10.1 (2.7) | Hunger:
| | | | | | | | G2: 9.9 (3.5) | G1: 8.5 (2.6) (P = NR)
| | | | | | | | (P = NS) | G2: 10.0 (3.2) (P = NR)
| | | | | | | | | Diff between groups (NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Wk 24:
| | | | | | | | | Hunger:
| | | | | | | | | G1: 7.5 (2.9) (P = NR)
| | | | | | | | | G2: 9.0 (3.7) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Restraint: | Wk 12 (end of tx)
| | | | | | | | G1: 7.0 (3.6) | Restraint:
| | | | | | | | G2: 7.1 (3.8) | G1: 9.4 (3.3) (P = NR)
| | | | | | | | (P = NS) | G2: 7.8 (4.4) (P = NR)
| | | | | | | | | Diff between groups (NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Wk 24:
| | | | | | | | | Restraint:
| | | | | | | | | G1: 10.5 (4.3) (P = NR)
| | | | | | | | | G2: 8.2 (4.8) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Abstinence for at least 2 wks by wk 12 (%):
| | | | | | | | | G1: 55%
| | | | | | | | | G2: 9%
| | | | | | | | | Diff between groups (P < 0.008)
| | | | | | | | | G1 greater than G2
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Randomly assigned according to 3.5 to 1 ratio to 12-wks of group CBT or waitlist control. G1: randomly assigned to one of three identical tx groups. Subjects who met clinical criteria of success (i.e., abstinence of binge-eating for at least the last 2 wks of tx, initiation of a min aerobic exercise program, and wt stabilization or wt loss for at least the last 4 wks of tx) by wk-12 were then provided with 12-wks of behavioral wt loss tx. Those who did not meet clinical criteria of success by the end of wk-12 received add 12-wks of CBT. | ANOVAs and repeated measures ANOVAs to assess between group diff for primary and secondary variables of interest | Score: | BES mean: | BES mean: | BDI, mean: | BDI, mean: | BMI, kg/m ^ 2 ^ mean: | BMI, kg/m ^ 2 ^ mean
Eldredge et al., 1997 | To assess the efficacy of CBT vs waitlist control in treating BED in obese individuals (additional analyses concerning extended tx for non-responders not reported since patients not randomized). | G1: CBT (N = 36) | Total: 45.2 (9.8) | DSM IV proposed criteria for BED; obese (BMI ≥ 27) | | | Poor | G1: 27.97 | G1: 17.07 (P = NR) | G1: 13.67 (NR) | G1: 9.17 (P = NR) | G1: 37.05 (NR) | G1: 36.29 (P = NR)
Setting: | | G2: Wl control (N = 10) | G1: NR | Exclusion: | | | Intent to treat: | G2: 29.38 | G2: 20.88 (P = NR) | G2: 14.38 (NR) | G2: 7.88 (P = NR) | G2: 43.35 (NR) | G2: 44.73 (P = NR)
Outpatient; Northern California, USA | | Enrollment: | G2: NR | Concurrent additional tx which might interfere with this study (i.e., wt loss program, anti-depressant meds, any meds that could influence wt); current drug or alcohol abuse; hx of purging within the last 6 mos; current major medical or psychiatric condition that could affect tx (i.e., pregnancy, psychosis, or severe suicidality). | | | NR | (P = NS) | Change over time (P < 0.0001) | (P = NS) | Change over time (P = 0.002) | Diff between groups (P = NS) | Diff between groups
Enrollment period: | | - 75 scheduled for dx interview after meeting requirements of preliminary telephone screening; - 10 subjects on waitlist for previous study re-interviewed; - 46 enrolled; - 37 remained at 24 wks | (P = NS) | | | | Blinding: | | Diff between groups (P = NS) | | Diff between groups (P = NS) | | (P = 0.03)
NR | | | Age of onset of overwt, yrs, mean (SD): | | | | No | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS) | | G1 better than G2
| | | Total: 15.8 (11.7) | | | | Adverse events: | | | | | | Diff between groups in change over time (P = NS)
| | | G1: NR | | | | NR | TFEQ restraint, mean: | TFEQ scales mean: | GSI, mean: | GSI, mean at 12-wks:
| | | G2: NR | | | | Funding: | Restraint: | Restraint: | G1: 0.63 (NR) | G1: 0.52 (P = NR)
| | | (P = NS) | | | | NIH | G1: 8.52 | G1: 11.26 (P = NR) | G2: 0.75 (NR) | G2: 0.47 (P = NR)
| | | Age of onset of binge-eating, yrs, mean (SD): | | | | | G2: 6.88 | G2: 9.38 (P = NR) | (P = NS) | Change over time (P = 0.06)
| | | Total: 22.0 (13.7) | | | | | (P = NS) | Change over time (P < 0.0002) | | Diff between groups (P = NS)
| | | G1: NR | | | | | | Diff between groups (P = NS) | | Diff between groups in change over time (P = NS)
| | | G2: NR | | | | | | Diff between groups in change over time (P = NS)
| | | (P = NS) | | | | | TFEQ Disinhibition mean: | TFEQ Disinhibition:
| | | Sex (N): | | | | | G1: 13.90 (NR) | G1: 10.94 (P = NR)
| | | Female: 44 | | | | | G2: 13.63 (NR) | G2: 12.63 (P = NR)
| | | Male: 2 | | | | | (P = NS) | Change over time (P < 0.0001)
| | | Race/ethnicity: | | | | | | Diff between groups (P = NS)
| | | NR | | | | | | Diff between groups in change over time (P = NS)
| | | Wt, kg, mean (SD): | | | | | TFEQ Hunger mean: | TFEQ Hunger:
| | | Total: 106.8 (28.2) | | | | | G1: 8.94 | G1: 6.65 (P = NR)
| | | G1: NR | | | | | G2: 9.5 | G2: 9.63 (P = NR)
| | | G2: NR | | | | | (P = NS) | Change over Time (P < 0.001)
| | | (P = NS) | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | % decrease in # of binge eating days by 12-wks, mean:
| | | | | | | | | G1: 68.2
| | | | | | | | | G2: 19.8
| | | | | | | | | Diff between groups (P = 0.046)
| | | | | | | | | G1 better than G2
| | | | | | | | | Treatment-responders by 12-wks:
| | | | | | | | | 50% of the treated sample (N = 18)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | G1: 90-minute group meetings (with 6 – 11 participants per group) held once a wk for 12 wks. 8 advanced clinical psychology grad students served as co-leaders. Protocol based on a BED therapist manual created by Telch and Agras (1992). | For certain analyses data from standard CBT and CBT SI were combined (and called active CBT) to compare with control group. To ensure adequate power, the study's apriori hypotheses were examined using planned orthogonal contrasts. For each set of planned orthogonal contrasts, group diffs were tested with mixed model ANOVA's. Group diff on dichotomous variables assessed with chi-square tests. Two sets of comparisons were performed: active CBT (G1 + G2) versus waitlist (G3) and standard CBT (G1) versus CBT-SI (G2). | Score: | Days binged (7-day recall) (SD): | Post-tx: | BDI (SD): | BDI (SD): | Body Mass Index, mean (SD): | Body Mass Index, mean (SD):
Gorin et al., 2003 | To evaluate effects of spouse involvement in group CBT for BED and replicate previous literature on effectiveness of CBT for BED. | G1: Standard CBT (N = 32) | 45.20 yrs (10.03) | Women, aged 18–65, meeting DSM IV criteria for BED, having BMI > = 25 and having a spouse or cohabiting partner who is willing to participate in study. | G2: standard CBT manual modified but tx goals the same; however, in CBT-SI goals included having both partners understand BED, perceive coping resources as available, agree about course of action and feel confident about ability to deal with BED. All partners required to attend all group meetings. In each session participants start by discussing eating problems and progress with their partners. Partners encouraged to participate in discussions. In add to regular homework, husbands set behavioral goals to assist wives in decreasing frequency of BE. | | Fair | G1: 3.81 (1.66) | Days binged (7-day recall) (SD): | G1: 18.71 (8.89) | G1: 14.76 (9.32) (P = NR) | G1: 38.72 (8.78) | G1: 38.65 (8.51) (P = NR)
Setting: | | G2: CBT-SI (N = 31) | Sex: | Exclusion: | G3: completed assessments at T1 and T2 and then entered tx. FU assessments at 6 mos. | | Intent to treat: | G2: 3.41 (2.09) | G1: 1.81 (1.97) (P = NR) | G2: 20.41 (9.96) | G2: 11.82 (9.42) (P = NR) | G2: 40.51 (8.29) | G2: 40.37 (8.33) (P = NR)
Outpatient Wt Control and Diabetes Research Center, Providence, RI, USA | | G3: Waitlist control group (CG) (N = 31) | Female: 100% | Engaged in binge purging behaviors > once a mo, met DSM IV criteria for AN, BN or EDNOS, receiving concurrent tx for wt loss, taking appetite suppressants and/or pregnant. | | | Yes | G3: 3.77 (1.82) | G2: 1.18 (1.76) (P = NR) | G3: 17.41 (9.93) | G3: 16.77 (9.54) (P = NR) | G3: 39.37 (7.53) | G3: 39.73 (7.79) (P = NR)
Enrollment period: | | Enrollment: | Race/ethnicity: | | | | Blinding: | (P = NS) | G3: 2.95 (1.84) (P = NR) | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR)
NR | | - 896 women responded to an advertisement; - 399 completed brief telephone screening; - 109 invited to complete baseline assessment; - 15 ineligible and excluded; - 94 blocked by binge eating frequency and randomly assigned to one of three conditions | Caucasian: 86% | | | | NA | | Diff between groups (P = NR) | | Diff between groups in change over time (P < 0.05) | | Diff between groups in change over time (P < 0.05)
| | | | | | | Adverse events: | | Diff between groups in change over time (P = 0.04) | | G1 and G2 better than G3 | | G1 and G2 better than G3
| | | | | | | NR | | G1 and G2 better than G3 | | Post tx: Standard CBT (G1) versus CBT-SI (G2) (*Means as above) | | Post tx: Standard CBT (G1) versus CBT-SI (G2) (*Means as above)
| | | | | | | Funding: | | Diff between G1 and G2 (P = NR) | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | | | | | Dissertation grant from Society for Science of Clinical Psychology and funding from Applied Behavioral Medicine Research Institute. | | Diff between G1 and G2 in change over time (P = NS) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | | | FU: | | FU (no data reported for waitlist grp): | | FU (no data reported for waitlist grp):
| | | | | | | | | Days binged (7-day recall) (SD): | | G1: 12.89 (8.05) (P = NR) | | G1: 37.83 (8.84) (P = NR)
| | | | | | | | | G1: 1.05 (1.43) (P = NR) | | G2: 12.24 (9.23) (P = NR) | | G2: 39.74 (8.67) (P = NR)
| | | | | | | | | G2: 0.67 (0.86) (P = NR) | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | | | | | | | G3: Data not provided | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Objective Binge episodes (SD): | Objective Binge episodes (SD):
| | | | | | | | G1: 7.61 (5.66) | G1: 2.44 (2.83) (P = NR)
| | | | | | | | G2: 9.55 (6.09) | G2: 3.32 (4.35) (P = NR)
| | | | | | | | G3: 8.47 (5.21) | G3: 5.87 (4.64) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Post tx: Standard CBT (G1) versus CBT-SI (G2) (*Means as above)
| | | | | | | | | Objective Binge episodes:
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | FU:
| | | | | | | | | Objective Binge episodes (SD):
| | | | | | | | | G1: 1.63 (2.09) (P = NR)
| | | | | | | | | G2: 3.50 (4.64) (P = NR)
| | | | | | | | | G3: Data not provided
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Binge abstinence (SD):
| | | | | | | | | G1+G2 (37%) (P = NR)
| | | | | | | | | G3 (9%) (P = NR)
| | | | | | | | | Diff between groups (P < 0.05) Active CBT higher percentage of abstinent participants.
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Post tx: Standard CBT (G1) versus CBT-SI (G2) (*Means as above):
| | | | | | | | | G1 (29%) (P = NR)
| | | | | | | | | G2 (46%) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | FU (no data reported for waitlist grp)
| | | | | | | | | FU:
| | | | | | | | | Binge abstinence (SD):
| | | | | | | | | G1 (47%) (P = NR)
| | | | | | | | | G2 (52%) (P = NR)
| | | | | | | | | G3: Data not provided
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | TFEQ Restraint, mean (SD): | TFEQ Restraint, mean (SD):
| | | | | | | | G1: 9.24 (4.01) | G1: 9.52 (4.30) (P = NR)
| | | | | | | | G2: 6.41 (2.91) | G2: 8.41 (3.32) (P = NR)
| | | | | | | | G3: 7.32 (3.96) | G3: 7.30 (4.73) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Post tx: Standard CBT (G1) versus CBT-SI (G2) (*Means as above)
| | | | | | | | | G1: diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | FU:
| | | | | | | | | G1: 12.11 (3.00) (P = NR)
| | | | | | | | | G2: 8.24 (3.00) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | TFEQ Disinhibition, mean (SD): | TFEQ Disinhibition, mean (SD):
| | | | | | | | G1: 12.48 (1.89) | G1: 10.86 (3.81) (P = NR)
| | | | | | | | G2: 13.14 (2.23) | G2: 11.55 (3.05) (P = NR)
| | | | | | | | G3: 13.45 (1.26) | G3: 13.23 (2.31) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | G1 and G2 better than G3
| | | | | | | | | Post tx: Standard CBT (G1) versus CBT-SI (G2) (*Means as above):
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | FU (no data reported for waitlist grp):
| | | | | | | | | G1: 9.74 (3.87) (P = NR)
| | | | | | | | | G2: 11.00 (3.39) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | TFEQ Hunger (SD): | TFEQ Hunger (SD):
| | | | | | | | G1: 8.81 (3.64) | G1: 7.14 (3.88) (P = NR)
| | | | | | | | G2: 10.77 (3.21) | G2: 9.23 (3.18) (P = NR)
| | | | | | | | G3: 9.82 (2.68) | G3: 9.86 (3.47) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.05)
| | | | | | | | | G1 and G2 better than G3
| | | | | | | | | Post tx: Standard CBT (G1) versus CBT-SI (G2) (*Means as above)
| | | | | | | | | TFEQ Hunger:
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | FU (no data reported for waitlist grp):
| | | | | | | | | TFEQ-hunger (SD):
| | | | | | | | | G1: 5.68 (3.62) (P = NR)
| | | | | | | | | G2: 8.71 (3.74) (P = NR)
| | | | | | | | | G3: Data not provided
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | 19 wkly sessions within 5 mos and self-management phase of 3 sessions. Sessions 2 hrs long and groups had 4 – 5 members. Therapy based on manualized tx for CBT for BN with emphasis on body image disturbance. All group sessions conducted by a PhD level clinical psychologist. Nutritionist and physical therapist also provided services. In initial part of tx, focus was on causes and factors maintaining binge eating for the individual and included interventions aimed at increasing motivation for change. | Multivariate generalized linear models for repeated measures used. Univariate FU tests done for sig multivariate results. Nonparametric tests analyzed changes over time for tx diffs at each time point. | Score: | Binges per wk in the past mo, mean (SD): | Binges per wk in past mo, mean (SD): | BDI, mean (SD): | BDI, mean (SD): | BMI kg/m ^ 2 ^ , mean (SD): | BMI, kg/m ^ 2 ^ , mean (SD):
Hilbert and Tuschen-Caffier, 2004 | Compare CBT with CBT-E and CBT along with CBT-C | G1: CBT-E (N = 14) | G1: 42.1 (12.1) | DSM IV criteria for BED except for frequency criterion (frequency of 1 day per wk over last 6 mos allowed) | For CBT-C condition: participants trained and given homework on cognitive restructuring of neg body related cognitions. For exposure condition, multiple body exposure sessions, including in vivo mirror exposure to one's whole body. Within both conditions, info and group discussions on body image, body wt, social aspects of obesity and exercise were conducted. | | Fair | G1: 2.9 (1.8) | Post-tx: | G1: 19.0 (8.6) | Post-tx | G1: 34.0 (10.2) | Post-tx:
Setting: | | G2: CBT-C (N = 14) | G2: 38.6 (8.5) | Exclusion: | | | Intent to treat: | G2: 3.4 (1.9) | G1: 0.6 (0.7) | G2: 16.0 (7.7) | G1: 12.8 (8.8) | G2: 36.4 (10.4) | G1: 33.1 (10.4)
Outpatient; Psychotherapeutic unit at University of Marburg, Germany. | | Enrollment: | (P = NS) | Pregnancy, presence of psychotic symptoms; substance dependence; suicidality; use of psychoactive meds or meds affecting body wt. | | | Yes | (P = NS) | G2: 1.0 (1.9) | (P = NS) | G2: 12.7 (9.0) | (P = NS) | G2: 37.2 (10.3)
Enrollment period: | | - Recruited through ads for free group therapy.; - 130 responded to ads and were screened for eligibility; - 77 eligible and invited for initial contact.; - 66 attended meeting; - 34 remained interested; - 2 excluded because of diagnostic status and 4 did not return for later appointments.; - Randomization after preparation for therapy. | Sex: | | | | Blinding: | | 4 mo FU, mean (SD): | | 4 mo FU, mean (SD): | | 4 mo FU, mean (SD):
NR | | | Female: 100% | | | | N/A | | G1: 1.2 (2.0) | | G1: 13.9 (8.7) | | G1: 33.6 (11.0)
| | | Race/ethnicity: | | | | Adverse events: | | G2: 0.5 (1.0) | | G2: 12.3 (6.9) | | G2: 36.4 (11.0)
| | | NR | | | | NR | | Change over time (P = 0.045) | | Change over time (P < 0.001) | | Change over time (P = NS)
| | | Age of first binge, yrs, mean (SD): | | | | Funding: | | Diff between groups (P = NR) | | Diff between groups (P = NR) | | Diff between groups (P = NR)
| | | G1: 21.7 (14.7) | | | | Deutshce Forschungsgemeinschaft DFG | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | G2: 18.7 (10.4) | | | | | Binge episodes, %: | Binge episodes:
| | | (P = NS) | | | | | G1: 16.7% | Post-tx
| | | Duration of BED, yrs, mean (SD): | | | | | G2: 16.7% | G1: 0%
| | | G1: 13.5 (10.7) | | | | | (P = NS) | G2: 0%
| | | G2: 17.7 (13.2) | | | | | | 4 mo FU, mean (SD):
| | | (P = NS) | | | | | | G1: 0%
| | | Education: | | | | | | G2: 16.6%
| | | University degree: | | | | | | Change over timeNR
| | | G1: 14.3% | | | | | | Diff between groups (P = NR)
| | | G2: 7.1% | | | | | | Diff between groups in change over time (P = NS)
| | | HS degree: | | | | | Video confrontation, neg automatic thoughts on one's body, mean (SD): | Video confrontation, neg automatic thoughts on one's body, mean (SD):
| | | G1: 35.7% | | | | | G1: 13.3 (5.9) | Post-tx:
| | | G2: 50.0% | | | | | G2: 17.4 (10.8) | G1: 9.7 (7.7)
| | | Secondary school degree: | | | | | (P = NS) | G2: 13.7 (11.7)
| | | G1: 50.0% | | | | | | 4 mo FU, mean (SD):
| | | G2: 42.9% | | | | | | G1: 8.8 (8.3)
| | | (P = NS) | | | | | | G2: 12.8 (7.0)
| | | Full syndrome BED: | | | | | | Change over time (P < 0.05)
| | | G1: 71.4% | | | | | | Diff between groups (P = NR)
| | | G2: 71.4% | | | | | | Diff between groups in change over time (P = NS)
| | | Subthreshold BED: | | | | | Test meal, mean (SD): | Test meal, neg automatic thoughts on eating, mean (SD):
| | | G1: 28.6% | | | | | G1: 5.0 (3.3) | Post-tx:
| | | G2: 28.6% | | | | | G2: 4.5 (3.2) | G1: 2.1 (1.5)
| | | (P = NS) | | | | | (P = NS) | G2: 6.7 (5.1)
| | | | | | | | | 4 mo FU, mean (SD):
| | | | | | | | | G1: 2.8 (2.7)
| | | | | | | | | G2: 3.0 (2.3)
| | | | | | | | | Change over time (P = NS)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE-Wt concern, mean (SD): | EDE-Wt concern, mean (SD):
| | | | | | | | G1: 3.2 (0.8) | Post-tx:
| | | | | | | | G2: 3.8 (1.1) | G1: 2.3 (1.9)
| | | | | | | | (P = NS) | G2: 2.3 (1.5)
| | | | | | | | | 4 mo FU, mean (SD):
| | | | | | | | | G1: 2.5 (1.7)
| | | | | | | | | G2: 2.2 (1.5)
| | | | | | | | | Change over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE- shape concern, mean (SD): | EDE- shape concern, mean (SD):
| | | | | | | | G1: 3.7 (0.7) | Post-tx:
| | | | | | | | G2: 3.7 (1.2) | G1: 2.6 (1.6)
| | | | | | | | (P = NS) | G2: 2.3 (1.5)
| | | | | | | | | 4 mo FU, mean (SD):
| | | | | | | | | G1: 2.8 (1.7)
| | | | | | | | | G2: 2.1 (1.3)
| | | | | | | | | Change over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Body Satisfaction Questionnaire, mean (SD): | Body Satisfaction Questionnaire, mean (SD):
| | | | | | | | G1: 120.7 (22.6) | Post-tx:
| | | | | | | | G2: 133.9 (20.0) | G1: 94.3 (37.8)
| | | | | | | | (P = NS) | G2: 104.8 (29.2)
| | | | | | | | | 4 mo FU, mean (SD):
| | | | | | | | | G1: 92.2 (35.8)
| | | | | | | | | G2: 97.4 (31.9)
| | | | | | | | | Change over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | EDE-Restraint, mean (SD):
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 0.9 (1.2)
| | | | | | | | | G2: 0.9 (1.2)
| | | | | | | | | 4 mo FU, mean (SD):
| | | | | | | | | G1: 1.0 (1.2)
| | | | | | | | | G2: 1.1 (1.3)
| | | | | | | | | Change over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE-eating concern, mean (SD): | EDE-eating concern, mean (SD):
| | | | | | | | G1: 0.7 (0.8) | Post-tx:
| | | | | | | | G2: 1.1 (1.0) | G1: 0.2 (0.3)
| | | | | | | | (P = NS) | G2: 0.4 (0.6)
| | | | | | | | | 4 mo FU, mean (SD):
| | | | | | | | | G1: 0.2 (0.3)
| | | | | | | | | G2: 0.4 (0.6)
| | | | | | | | | Change over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Recovered (abstinent for last 28 days):
| | | | | | | | | Post-tx:
| | | | | | | | | G1: 33.3%
| | | | | | | | | G2: 75%
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | 4 mo FU:
| | | | | | | | | G1: 50.0%
| | | | | | | | | G2: 66.7%
| | | | | | | | | Diff between groups (P = NS)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | CBT: wkly 90-minutes group sessions for 4 mos based on CBT tx for BED (based on Telch et al., 1990) facilitated by experienced RDs. | ANOVA and chi-square for comparison of completers and noncompleters. Kruskal-Wallace ANOVA by ranks to analyze binge days. Repeated Msrs ANOVA for BMI. Bivariate correlations for exploratory analyses. | Score: | Binge days, mean (SD): | Binge Days, mean (SD): | BDI, mean (SD): | BDI, mean (SD): | Wt: | Change in BMI (SD):
Pendleton et al., 2002 | To evaluate the effects of adding exercise and maintenance to CBT for BED in obese women. | G1: CBT with exercise and maintenance (N = 28) | 45 (8.3) | Female; age: 25–60; > 30 lbs overwt; profile for BE as per QEWP-R; hx of sedentary lifestyle and occ. Also - $200 deposit and physician clearance to participate. | Exercise: info and instructions on incorporating and maintaining exercise in routine; provided membership to a center and encouraged to gradually increase aerobic exercise; expectations were at least 45 minutes per session, 3 x per wk (attendance was recorded). | | Poor | G1: 4.2 (2.3) | 4 mos: | G1: 15.7 (9.7) | 4 mos: | 97.2 (17.8) kg | 4 mos:
Setting: | | G2: CBT with exercise, without maintenance (N = 27) | Sex: | Exclusion: | Maintenance: 12 biwkly meetings over 6 mos (mos 4-10; exercisers continued to meet and exercise, CBT only continued with sessions only). FU at 16 mos. | | Intent to treat: | G2: 4.6 (2.1) | G1: 0.6 (1.1) (P = NR) | G2: 18.1 (10.7) | G1: 6.4 (5.5) (P = NR) | BMI, kg/m ^ 2 ^ , mean: | G1: -1.04 (2.1) (P = NR)
NR | | G3: CBT without exercise and with maintenance (N = 27) | Female: 100% | No hx of cardiovascular disease, diabetes, metabolic disorder, GI disorder/surgery; nonsmoker; not pregnant/lactating; not receiving tx for psych problems or major depression; no hx of drug abuse | | | No | G3: 4.6 (1.9) | G2: 1.0 (1.3) (P = NR) | G3: 19.0 (10.5) | G2: 7.3 (7.8) (P = NR) | 36.2 (6.5) kg/m2 | G2: -0.46 (1.3) (P = NR)
Enrollment period: | | G4: CBT without exercise or maintenance (N = 28) | Race/ethnicity: | | | | Blinding: | G4: 4.8 (2.0) | G3: 2.4 (2.2) (P = NR) | G4: 18.0 (7.2) | G3: 9.7 (6.2) (P = NR) | (P = NS) | G3: -0.11 (1.2) (P = NR)
NR | | Enrollment: | Caucasian: 76% | | | | No | (P = NS) | G4: 1.9 (2.0) (P = NR) | | G4: 11.8 (9.6) (P = NR) | | G4: 0.77 (1.3) (P = NR)
| | - 114 enrolled; - 26 did not return after baseline assessment: G1: N = 4 G2: N = 7 G3: N = 4 G4: N = 11; - 84 completed 6 mos | Black: 13% Black | | | | Adverse events: | | Diff between groups (P = 0.004) | | Diff between groups NR | | 10 mos:
| | Completion rate: | Mexican Am: 8% | | | | NR | | Diff between G1 vs G4 (P = 0.039) | | G1 + G2 change over time (P = 0.007) | | G1: -2.53 (4.0) (P = NR)
| | 1 in each group did not complete all assessments. | Other: 3% | | | | Funding: | | G1 better than G4 | | 10 mos: | | G2: -0.12 (16) (P = NR)
| | G1: 24 | (P = NS) | | | | NIDDK | | Diff between groups in change over time | | G1: 5.2 (5.1) (P = NR) | | G3: -83 (2.4) (P = NR)
| | G2: 20 | | | | | | | Exercisers (G1 + G2) > non-exercisers (G3 + G 4) (P = 0.001) | | G2: 11.0 (1.07) (P = NR) | | G4: 0.54 (2.0) (P = NR)
| | G3: 23 | | | | | | | Maintenance (G1 + G3) vs no maintenance (G2 + G4) (P = NS) | | G3: 9.1 (8.1) (P = NR) | | 16 mos:
| | G4: 17 | | | | | | | 10 mos: | | G4: 8.7 (5.6) (P = NR) | | G1: -2.26 (3.9) (P = NR)
| | | | | | | | | G1: 0.5 (0.8) | | Diff between G1 vs G2: | | G2: -0.75 (2.4) (P = NR)
| | | | | | | | | G2: 1.0 (1.3) | | (P = 0.025) | | G3: -0.24 (3.0) (P = NR)
| | | | | | | | | G3: 1.3 (1.6) | | Diff between groups in change over time (P = NR) | | G4: 1.33 (2.0) (P = NR)
| | | | | | | | | G4: 2.0 (1.6) | | 16 mos: | | Change over entire period: G1 + G2 vs G3 + G4 (P = 0.004)
| | | | | | | | | Change over time (P = NR) | | G1: 5.1 (5.9) (P = NR) | | G1 + G2 better than G3 + G4
| | | | | | | | | Diff between groups (P = 0.018). diff between G1 vs G4: | | G2: 8.2 (8.6) (P = NR) | | G1 + G3 vs G2 + G4 (P = 0.006). G1 + G3 better than G2 + G4.
| | | | | | | | | (P = 0.002) | | G3: 8.0 (7.7) (P = NR) | | G1 vs G4 (P = 0.001)
| | | | | | | | | G1 better than G4 | | G4: 10.4 (8.2) (P = NR) | | G1 better than G4
| | | | | | | | | Diff between groups in change over time | | Diff between G1 + G3 vs G2 + G4
| | | | | | | | | Exercisers (G1 + G2) > non-exercisers (G3 + G 4) (P = 0.012) | | (P = NS)
| | | | | | | | | Maintenance (G1 + G3) vs no maintenance (G2 + G4) (P = NS). | | Diff between groups in change over time (P = NR)
| | | | | | | | | 16 mos:
| | | | | | | | | G1: 1.0 (1.7) (P = NR)
| | | | | | | | | G2: 0.8 (1.4) (P = NR)
| | | | | | | | | G3: 1.8 (2.2) (P = NR)
| | | | | | | | | G4: 2.5 (1.8) (P = NR)
| | | | | | | | | Change over time (P = NR)
| | | | | | | | | Diff between groups (P = 0.006)
| | | | | | | | | Diff between G1 vs G4 (P = 0.007); G1 better than G4
| | | | | | | | | Diff between groups in change over time
| | | | | | | | | Exercisers (G1 + G2) > non-exercisers (G3 + G 4) (P = 0.002)
| | | | | | | | | Maintenance (G1 + G3) vs no maintenance (G2 + G4) (P = NS)
| | | | | | | | | Abstinence (no binge days):
| | | | | | | | | 4 mos:
| | | | | | | | | G1: 67%
| | | | | | | | | G2: 50%
| | | | | | | | | G3: 22%
| | | | | | | | | G4: 41%
| | | | | | | | | (P = NR)
| | | | | | | | | 10:00
| | | | | | | | | G1: 63%
| | | | | | | | | G2: 45%
| | | | | | | | | G3: 43%
| | | | | | | | | G4: 23%
| | | | | | | | | (P = NR)
| | | | | | | | | 16 mos:
| | | | | | | | | G1: 58%
| | | | | | | | | G2: 65%
| | | | | | | | | G3: 39%
| | | | | | | | | G4: 18%
| | | | | | | | | Diff between groups (P = NR)
Author, yr: | Research objective: | Groups (N = 36): | Age, mean (SD): | Inclusion: | Inpatient, lasting 6 wks; Assessments administered at baseline, post-tx, and 6 mo FU. | Power analysis revealed low/medium power due to small sample and high SD. | Score: | NR | 6 mo FU: | | Post-tx: | | Post-tx:
Riva et al., 2003 | To compare psychological and eating-related outcomes of ECT, CBT, NG, and waitlist control in patients with BED at 6 mo FU. | G1: ECT (N = NR) | 33.07 (8.08) | Women aged 18 to 50; met DSM IV criteria for BED at least 6 mos; written and informed consent to participate | NG: 5 wkly groups held by dieticians, low-calorie diet and physical training; ECT: NG plus 15 additional, sessions over 6 wks (5 wkly group, 10 bi-wkly VREDIM). CBT:NG plus 15 CBT sessions (5 wkly group, 10 bi-wkly individual. | Accordingly, repeated and independent measures were assessed using marginal homogeneity test, an exact measure, non-parametric algorithm reliable with small, sparse or tied data. | Poor | | Bulimia scores, EDI: | State Anxiety scores, | State Anxiety scores, | Wt, kg (SD): | Wt, kg (SD):
Setting: | | G2: CBT (N = NR) | Sex: | Exclusion: | | | Intent to treat: | | G1: 9.33 | STAI X2: | STAI X2: | G1: 103.7 (17.2) | G1: 97.2 (15.6) (P = NR)
Inpatient; Eating Disorders Unit, Istituto Auxologico Italiano, Verbania, Italy | | G3: NG (N = NR) | Female: 100% | Concurrent: severe psychiatric disturbance, involvement in other tx including meds, medical condition not related to BED | | | NR | | G2: 14.56 | G1: 49.44 | G1: 36.77 (P = NS) | G2: 109.3 (10.5) | G2: 102.1 (9.14) (P = NR)
Enrollment period: | | G4: waitlist (N = NR) | Race/ethnicity: | | | | Blinding: | | G3: 18.11 | G2: NR | G2: NR (P = NS) | G3: 103.8 (21.3) | G3: 103.8 (21.3) (P = NR)
NR | | Enrollment: | NR | | | | NR | | G4: NR | G3: 49.77 | G3: 38.77 (P = 0.013) | G4: NR | G4: NR
| | - 120 consecutive patients screened; - 36 met criteria, and consented | Wt, kg, mean (SD): | | | | Adverse events: | | Diff over time (P = NR) | G4: NR | G4: NR (P = NS) | (P = NS) | Diff over time (P = NR) reported as sig in text
| | | 105.44 (17.73) | | | | NR | | Diff between groups (P < 0.05) | (P = NS) | Diff between groups (P = NR) | | Diff between groups (P = NS)
| | | Ht, cm, mean (SD): | | | | Funding: | | G1 better than G2 and G3 | BDI scores: | Diff between groups in change over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | 1.62 (0.06) | | | | Commission of the European Communities (CEC); specifically, the IST program through the VEPSY Updated research project. | | Diff between groups in change over time (P = NR) | G1: 22.23 | BDI scores: | | 6 mo FU:
| | | BMI, kg/m^2^, mean (SD): | | | | | | Resisting Temptations scores, DIET: | G2: 20.55 | G1: 8.11 (P = 0.008) | | G1: NR
| | | 39.80 (6.10) | | | | | | G1: 19.11 | G3: NR | G2: 12.11 (P = 0.05) | | G2: NR
| | | | | | | | | G2: 12.00 | G4: NR | G3: NR (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | G3: 10.89 | (P = NS) | G4: NR (P = NS) | | Diff between groups in change over time (P = NR)
| | | | | | | | | G4: NR | | Diff between groups (P = NR)
| | | | | | | | | Diff over time (P = NR) | | Diff between groups in change over time (P = NR)
| | | | | | | | | Diff between groups (P < 0.05)
| | | | | | | | | G1 better than G2 and G3
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Body Satisfaction Scale, Total scores:
| | | | | | | | | G1: 8.5
| | | | | | | | | G2: 17.3
| | | | | | | | | G3: 16.2
| | | | | | | | | G4: NR
| | | | | | | | | Diff over time (P = NR)
| | | | | | | | | Diff between groups (P = < 0.05)
| | | | | | | | | G1 better than G2 and G3
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Abstinence, bingeing:
| | | | | | | | | G1: 77%
| | | | | | | | | G2: 56%
| | | | | | | | | G3: 22%
| | | | | | | | | G4: NR
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Over 20 wks, tx was delivered at wkly, group 2hr sessions to teach DBT skills; tx manual was adapted from Linehan's DBT for borderline personality disorder | T-test or chi-square analyses were completed to compare baseline measures, as well as dropouts versus tx completers; tx outcomes were assessed using a one-way ANCOVA with baseline measures as covariates. | Score: | Note: Means are reported; square root transformations were used in analyses. | | BDI, median (SD): | BDI, median (SD): | Wt, lbs, median (SD): | Wt, lbs, median (SD):
Telch, Agras and Linehan, 2001 | Assess the efficacy of DBT tx compared to a waitlist control in women with BED. | G1: DBT (N = 22) | 50 (9.1) | Age 18 to 65; met full DSM IV diagnostic research criteria for BED | For all participants, assessments, and ht and wt measures were taken at baseline, post-tx (20 wks), 3-, and 6-mo FU. | Analyses were restricted to those who completed tx. | Fair | Binge days, per 28 days, median (SD): | Binge days, per 28 days, median (SD): | G1: 12.8 (7.4) | G1: 9.9 (10.0) (P = NR) | G1: 214.7 (49.8) | G1: 209.2 (49.8) (P = NR)
Setting: | | G2: Waitlist (N = 22) | Age of drop-outs, mean (SD): | Exclusion: | | | Intent to treat: | G1: 10.5 (9.0) | G1: 0 (0) (P = NR) | G2: 13.8 (9.1) | G2: 12.8 (8.3) (P = NR) | G2: 223.4 (37.1) | G2: 223.8 (37.1) (P = NR)
Outpatient; Stanford University, USA | | Enrollment: | Drop-outs: 41.0 (10.5) | Current involvement in psychotherapy, wt loss tx, or use of psychotropic meds; current substance abuse or dependence; current suicidality or psychosis; pregnancy | | | No | G2: 14.0 (5.0) | G2: 8.5 (10.0) (P = NR) | (P = NS) | Diff between groups (P = NR) | (P = NS) | Diff between groups (P = NR)
Enrollment period: | | - 465 screened by telephone; - 88 scheduled for clinical screening; 77 attended; - 44 enrolled and randomized; - G1: 18 completed through 6-mo FU; G2: 14 accepted waitlist tx, and 10 completed. | Non-drop-outs: 50. (9.2) | | | | Blinding: | (P = NS) | Diff between groups (P = NR) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
NR | | | (P < 0.04) | | | | No | | Diff between groups in change over time (P < 0.001) | RSE, median (SD): | RSE, median (SD):
| | | Sex: | | | | Adverse events: | | G1 better than G2 | G1: 26.0 (6.8) | G1: 29.4 (6.1)
| | | Female: 100% | | | | During FU period, 3 women in G1 were treated with either psychotherapy or meds for a major depressive episode, and 1 enrolled in a very-low-calorie diet program. | Binge episodes, per 28 days, median (SD): | Binge episodes, per 28 days, median (SD): | G2: 28.9 (5.0) | G2: 29.2 (4.5)
| | | Race/ethnicity: | | | | Funding: | G1: 11.5 (10.8) | G1: 0 (0) (P = NR) | | Diff between groups (P = NR)
| | | Caucasian: 94% | | | | NIMH | G2: 14.5 (7.5) | G2: 10.0 (14.0) (P = NR) | | Diff between groups in change over time (P = NS)
| | | Marital Status: | | | | | (P = NS) | Diff between groups (P = NR)
| | | Married: 47% | | | | | | Diff between groups in change over time (P < 0.001)
| | | Divorced: 35% | | | | | | G1 better than G2
| | | Never married: 18% | | | | | EDE, Wt Concerns, median (SD): | EDE, Wt Concerns, median (SD):
| | | Educational Status: | | | | | G1: 3.4 (1.1) | G1: 2.2 (0.9) (P = NR)
| | | Completed college: 70% | | | | | G2: 3.6 (0.6) | G2: 3.1 (1.0) (P = NR)
| | | Completed HS: 100% | | | | | (P = NS) | Diff between groups (P = NR)
| | | Lifetime psychopathology: | | | | | | Diff between groups in change over time (P < 0.02)
| | | Major depression: 38% | | | | | | G1 better than G2
| | | Anxiety disorders: 35% | | | | | EDE, Shape Concerns (SD): | EDE, Shape Concerns (SD):
| | | Psychotic disorders: 3% | | | | | G1: 3.7 (0.7) | G1: 2.3 (0.9) (P = NR)
| | | Bulimia nervosa: 6% | | | | | G2: 4.0 (0.8) | G2: 3.1 (1.0) (P = NR)
| | | Substance abuse or dependence: 27% | | | | | (P = NS) | Diff between groups (P = NR)
| | | Current psychopathology: | | | | | | Diff between groups in change over time (P < 0.03)
| | | Major depression: 9% | | | | | | G1 better than G2
| | | Anxiety disorder: 18% | | | | | EDE, Eating Concerns, median (SD): | EDE, Eating Concerns, median (SD):
| | | Personality disorder: 27% | | | | | G1: 1.6 (1.1) | G1: 0.4 (0.4) (P = NR)
| | | Age of onset, binge eating, yrs, mean (SD): | | | | | G2: 1.8 (1.0) | G2: 1.4 (0.9) (P = NR)
| | | 20.9 (11.7) | | | | | (P = NS) | Diff between groups (P = NR)
| | | Duration of binge eating, yrs, mean (SD): | | | | | | Diff between groups in change over time (P < 0.001)
| | | 29.2 (11.7) | | | | | | G1 better than G2
| | | BMI, kg/m^2^, mean (SD): | | | | | EDE, Restraint, median (SD): | EDE, Restraint, median (SD):
| | | 36.4 (6.6) | | | | | G1: 1.6 (1.0) | G1: 1.4 (1.0) (P = NR)
| | | | | | | | G2: 1.9 (1.1) | G2: 1.8 (1.3) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | BES, median (SD): | BES, median (SD):
| | | | | | | | G1: 28.8 (6.1) | G1: 15.7 (9.4) (P = NR)
| | | | | | | | G2: 31.8 (6.0) | G2: 28.2 (8.3) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P < 0.001)
| | | | | | | | | G1 better than G2
| | | | | | | | EES, Anxiety, median (SD): | EES, Anxiety, median (SD):
| | | | | | | | G1: 2.3 (0.9) | G1: 1.5 (0.9) (P = NR)
| | | | | | | | G2: 2.7 (0.6) | G2: 2.4 (1.0) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EES, Depression, median (SD): | EES, Depression, median (SD):
| | | | | | | | G1: 3.0 (0.7) | G1: 2.4 (1.0) (P = NR)
| | | | | | | | G2: 3.3 (0.7) | G2: 3.0 (0.8) (P = NR)
| | | | | | | | (P = NS) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | Both: 20 90-minutes wkly group sessions and 3 individual sessions. Wkly personalized written feedback detailing progress. Both groups manual-based and led by two therapists. | GEE approach. Used to test hypotheses about tx effects, time course and tx x time interactions with linear, quadratic and cubic components of time as the within-subjects factors and tx and interactions between time components and tx as between-subjects factors. Primary analyses included post tx and FU time points for three primary outcomes: recovered (no objective binge episodes in the last mo), improved (fewer than 4 days of objective binge episodes in the last mo) and being at or below a comparative level of eating disorder attitudes and behaviors. | Score: | Binge days, mean (SD): | Binge days, mean (SD): | Total GSI, mean (SD): | Total GSI, mean (SD): | BMI, mean (SD): | BMI, mean (SD):
Wilfley et al., 2002 | Compare effects of group CBT and group IPT on overwt individuals with BED. | G1: CBT (N = 81) | G1: 45.6 (9.6) | DSM IV research criteria for BED: avg of ≥2 days of binge eating per wk for at least 6 mos, marked distress regarding binge eating, at least 3 of 5 associated behavioral features (e.g., eating when not physically hungry), no regular use of inappropriate compensatory behavior, age: 18 – 65, BMI: 27 – 48 kg/m^2.^ | G1: 3 phases focusing on behavioral strategies, cognitive skills and relapse prevention. G2: focused on problem resolution within 4 social domains: Grief, interpersonal role disputes, role transitions and interpersonal deficits. | | Good | G1: 17.3 (6.9) | Post tx | G1: 43.3 (7.8) | Post tx: | G1: 37.4 (5.3) | Post tx
Setting: | | G2: IPT (N = 81) | G2: 44.9 (9.6) | Exclusion: | | | Intent to treat: | G2: 16.3 (7.2) | G1: 0.6 (1.6) (P < 0.001) | G2: 42.0 (8.9) | G1: 32.8 (8.8) (P < 0.001) | G2: 37.4 (5.1) | G1: 37.5 (5.3) (P = NS)
Outpatient; Eating disorder clinics at Yale U and at San Diego State U, USA | | Enrollment: | (P = NS) | Pregnant or planning to become pregnant, taking wt affecting or psychotropic meds, psychiatric conditions warranting immediate tx (e.g., psychotic symptoms, substance dependence or suicidality) and currently enrolled in psychotherapy or wt loss program. | | | Yes | (P = NS) | G2: 0.9 (2.0) (P < 0.001) | (P = NS) | G2: 32.3 (8.5) (P < 0.001) | (P = NS) | G2: 37.2 (5.2) (P = NS)
Enrollment period: | | - 974 individuals expressed interest; - 320 met criteria based on phone screens; - 195 met criteria after being interviewed; - 162 interested, eligible and randomized; - Participants randomly assigned to two groups of 9 participants each within 9 cohorts; - 146 completed tx and some assessments; - 133 completed all three FU CBT (N = 65); IPT (N = 68) | Sex: | | | | Blinding: | | Diff between groups (P = NS) | | Diff between groups (P = NS) | | Diff between groups (P = NS)
NR | | | Female: | | | | NA | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | G1: 82.7% | | | | Adverse events: | | 4 mos post tx vs. post-tx: | | 4 mos post tx: | | 4 mos post tx vs. post-tx:
| | | G2: 82.7% | | | | NR | | G1: 2.0 (4.6) (GEE quadratic: P < 0.001, GEE cubic: P = 0.002) | | G1: 33.0 (8.4) | | G1: 37.4 (5.3)
| | | (P = NS) | | | | Funding: | | G2: 1.5 (3.9) (GEE quadratic: P < 0.001, GEE cubic: P = 0.002) | | G2: 33.2 (10.9) | | G2: 36.6 (5.3)
| | | Race/ethnicity: | | | | NIMH | | Diff between groups (P = NS) | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | White: | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | G1: 93.9% | | | | | | 8 mos post tx vs. post-tx: | | 8 mos post tx | | 8 mos post tx vs. post-tx:
| | | G2: 91.4% | | | | | | G1: 2.1 (5.0) (GEE quadratic P < 0.001) | | G1: 31.9 (9.7) | | G1: 37.5 (5.1)
| | | (P = NS) | | | | | | GEE cubic (P = 0.002) | | G2: 32.7 (10.6) | | G2: 36.4 (5.5)
| | | AA: | | | | | | G2: 1.9 (4.5) (GEE quadratic (P < 0.001) | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | G1: 3.7% | | | | | | GEE cubic (P = 0.002) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | G2: 3.7% | | | | | | Diff between groups (P = NR) | | 12 mos post tx: | | 12 mos post tx vs. post-tx:
| | | (P = NS) | | | | | | Diff between groups in change over time (P = NS) | | G1: 32.0 (8.9) | | G1: 37.2 (5.1)
| | | Hisp: | | | | | | 12 mos post tx vs. post-tx: | | G2: 30.7 (10.6) | | G2: 36.3 (5.4)
| | | G1: 1.2% | | | | | | G1: 1.7 (4.3) (P = NR) | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | G2: 4.9% | | | | | | G2: 1.2 (2.6) (P = NR) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | (P = NS) | | | | | | Diff between groups (P = NR) | | | | Linear main effect of time since FU (P = 0.008)
| | | Native American: | | | | | | Diff between groups in change over time (P = NS)
| | | G1: 1.2% | | | | | EDE Restraint, mean (SD): | EDE Restraint, mean (SD): | SCL Depression, mean (SD): | SCL Depression, mean (SD):
| | | G2: 0% | | | | | G1: 1.8 (1.2) | Post tx | G1: 44.3 (8.3) | Post tx:
| | | (P = NS) | | | | | G2: 2.1 (1.3) | G1: 0.9 (0.9) (P = 0.001) | G2: 42.4 (9.6) | G1: 34.8 (7.9) (P < 0.001)
| | | Age at onset of disorder, yrs, mean (SD): | | | | | (P = NS) | G2: 1.5 (1.1) (P = 0.001) | (P = NS) | G2: 33.6 (8.6) (P < 0.001)
| | | G1: 24.1 (13.5) | | | | | | Diff between groups (P = 0.001) | | Diff between groups (P = NS)
| | | G2: 25.7 (12.9) | | | | | | Diff between groups in change over time (P < 0.001) | | Diff between groups in change over time (P = NS)
| | | (P = NS) | | | | | | G2 better than G1 | | 4 mos post tx:
| | | DSM III-R current Mood dx: | | | | | | 4 mos post tx: | | G1: 34.2 (8.3)
| | | G1: 25.9% | | | | | | G1: 0.9 (0.9) (P = 0.001) | | G2: 34.6 (10.6)
| | | G2: 18.5% | | | | | | G2: 1.3 (1.2) (P = 0.001) | | Diff between groups (P = NS)
| | | (P = NS) | | | | | | Diff between groups (P = 0.04) | | Diff between groups in change over time(P = NS)
| | | DSM III-R current anxiety dx: | | | | | | Diff between groups in change over time (P = 0.04); G1 better than G2 | | 8 mos post tx:
| | | G1: 12.3% | | | | | | 8 mos post tx: | | G1: 33.3 (8.6)
| | | G2: 13.6% | | | | | | G1: 0.8 (0.8) (P = 0.001) | | G2: 34.4 (10.7)
| | | (P = NS) | | | | | | G2: 1.2 (1.2) (P = 0.001) | | Diff between groups (P = NS)
| | | DSM III-R current substance use dx: | | | | | | Diff between groups (P = 0.08) | | Diff between groups in change over time (P = NS)
| | | G1: 6.2% | | | | | | Diff between groups in change over time (P = 0.04) | | 12 mos post tx:
| | | G2: 1.2% | | | | | | 12 mos post tx: | | G1: 33.1 (8.2)
| | | (P = NS) | | | | | | G1: 1.0 (1.1) | | G2: 32.2 (10.3)
| | | Any current Axis I DSM III-R dx: | | | | | | G2: 1.3 (1.3) | | Diff between groups (P = NS)
| | | G1: 37.0% | | | | | | Diff between groups (P = NS) | | Diff between groups in change over time(P = NS)
| | | G2: 29.6% | | | | | | Diff between groups in change over time (P = 0.04) | | Diff between groups in change over time (P = NS)
| | | (P = NS) | | | | | EDE Shape Concern, mean (SD): | EDE Shape Concern, mean (SD):
| | | Any current Axis II DSM III-R dx: | | | | | G1: 3.8 (1.0) | Post tx
| | | G1: 37.0% | | | | | G2: 3.8 (0.9) | G1: 2.3 (1.4) (P < 0.001)
| | | G2: 38.3% | | | | | (P = NS) | G2: 2.4 (1.1) (P < 0.001)
| | | (P = NS) | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 4 mos post tx:
| | | | | | | | | G1: 2.3 (1.2) (P = NS)
| | | | | | | | | G2: 2.4 (1.2); (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 8 mos post tx:
| | | | | | | | | G1: 2.3 (1.3) (P = NS)
| | | | | | | | | G2: 2.2 (1.2) (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 12 mos post tx:
| | | | | | | | | G1: 2.2 (1.3) (P = NS)
| | | | | | | | | G2: 2.2 (1.3) (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE Wt Concern, mean (SD): | EDE Wt Concern, mean (SD):
| | | | | | | | G1: 3.3 (1.1) | Post tx
| | | | | | | | G2: 3.2 (1.1) | G1: 2.0 (1.2) (P < 0.001)
| | | | | | | | (P = NS) | G2: 2.1 (1.2) (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 4 mos post tx:
| | | | | | | | | G1: 2.0 (1.1) (P = NS)
| | | | | | | | | G2: 2.2 (1.3) (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 8 mos post tx:
| | | | | | | | | G1: 2.1 (1.2) (P = NS)
| | | | | | | | | G2: 1.9 (1.1) (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 12 mos post tx:
| | | | | | | | | G1: 1.9 (1.3) (P = NS)
| | | | | | | | | G2: 1.9 (1.3) (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | EDE Eating Concern, mean (SD): | EDE Eating Concern, mean (SD):
| | | | | | | | G1: 2.4 (1.2) | Post tx
| | | | | | | | G2: 2.3 (1.5) | G1: 0.6 (0.8) (P < 0.001)
| | | | | | | | (P = NS) | G2: 0.7 (0.8) (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 4 mos post tx:
| | | | | | | | | G1: 0.6 (0.8) (P = NS)
| | | | | | | | | G2: 0.8 (1.0) (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 8 mos post tx:
| | | | | | | | | G1: 0.6 (0.7) (P = NS)
| | | | | | | | | G2: 0.7 (0.9) (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 12 mos post tx:
| | | | | | | | | G1: 0.6 (0.8) (P = NS)
| | | | | | | | | G2: 0.6 (0.9) (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Abstinence from binge-eating:
| | | | | | | | | Post tx
| | | | | | | | | G1: (82%) (P = NR)
| | | | | | | | | G2: (74%) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 12 mos post tx:
| | | | | | | | | G1: (72%) (P = NR)
| | | | | | | | | G2: (70%) (P = NR)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)

Evidence Table 13. Self-help trials for binge eating disorder

| | | | | | | | Eating Related Measures | | Psychological/Psychiatric Measures | | Biomarkers
Study Description | Objective | Design | Patient Characteristics | Inclusion/Exclusion Criteria | Treatment | Statistical Methods | Quality | Baseline | Outcomes | Baseline | Outcomes | Baseline | Outcomes
Author, yr: | Research objective: | Groups: | Age, yrs mean (SD) (range): | Inclusion: | 12 wks of a guided self-help or a pure cognitive-behavioral self-help program for binge-eating; In the pure self-help condition, subjects sent a copy of Overcoming Binge Eating and asked to follow program as best as possible on their own; In the guided self-help, subjects received 6-8 25-minute sessions with trained facilitator who provided assistance in adhering to the program outlined in Overcoming Binge Eating; Outcome variables assessed after 12 wks of tx in all 3 groups, and at 3-mo, and 6-mo FU for the two tx groups only. | Primary analyses included repeated measures ANOVAs and post-hoc comparisons to test between group diffs over course of the study; Chi-square tests used to test between group diffs in remission/abstinence rates. | Score: | Binge eating/28 days, mean (SD): | Binge eating/28 days, mean (SD): | GSI, mean (SD): | GSI, mean (SD): | Wt, kg, mean (SD): | Wt, kg, mean (SD):
Carter and Fairburn, 1998 | To assess effectiveness of two self-help programs for treating BED symptoms in comparison to a waitlist control. In addition to evaluating changes in eating- and wt-related outcomes, authors investigated potential group diffs in overall psychiatric symptom reporting and in knowledge of the educational content of the self-help materials. | G1: guided self-help (N = unclear) | Total Sample: | DSM IV and EDE criteria for BED including wkly objective BE over the last 3 mos without compensatory behaviors; aged: 18-65 | | | Good | G1: 17.8 (10.6) | 12 wks (end of tx) | G1: 0.9 (0.6) | 12 wks (end of tx): | Total sample: 85.8 (19.7) | G1: NR
Setting: | | G2: pure self-help (N = unclear) | 39.7 (10.0) (21-59) | Exclusion: | | | Intent to treat: | G2: 19.7 (12.9) | G1: 4.3 (7.8) (P = 0.01) | G2: 1.3 (0.8) | G1: 0.7 (0.6) (P = 0.01) | G1: NR | G2: NR
Single center; outpatient; Dept. of Psychiatry, University of Oxford, UK | | G3: waitlist control (N = unclear) | (P = NS) | Pregnancy; medical disorder or tx known to impact eating or wt; BN or AN; previous tx for binge-eating; current psychiatric tx | | | Yes | G3: 21.6 (12.5) | G2: 9.3 (11.7) (P = 0.01) | G3: 1.2 (0.8) | G2: 0.8 (0.6) (P = 0.01) | G2: NR
Enrollment period: | | Enrollment: | Sex: | | | | Blinding: | (P = NS) | G3: 13.5 (10.3) (P = NS) | (P = NS) | G3: 1.2 (0.7) (P = NS)
NR | | - 234 potential subjects responded to media advertisements and received an initial phone screen; - 91 were invited for an in-person assessment interview; - 72 were enrolled and randomized into the two self-help tx conditions; - 65 remained after 12 wks (G1 = 8 and G3 = 1; P = NR) | Female: 100% | | | | NA | | Diff between groups | | Diff between groups
| | * Group numbers inconsistent in text and figures: text indicates 72 randomized; tables and figures refer to total N = 93. | Race/ethnicity: | | | | Adverse events: | | G1 vs G3 (P = 0.001) | | G1 vs G3 (P = 0.003)
| | | White: 97% | | | | NR | | G1 better than G3 | | G1 better than G2
| | | Age of onset, yrs, mean (SD): | | | | Funding: | | G2 vs G3 (P < 0.05) G2 better than G3 | | G2 vs G3 (P = 0.04)
| | | 23.6 (11.1) | | | | Wellcome Prize Studentship and Wellcome Principal Fellowship | | G1 vs. G2 (P = NS) | | G1 better than G3
| | | (P = NS) | | | | | | Diff between groups in change over time (P = NR) | | G1 vs G2 (P = NS)
| | | Medically obese (BMI>30): | | | | | | 3-mos: | | Diff between groups in change over time (P = NS)
| | | 60% | | | | | | G1: 3.6 (3.5) (P = NS) | | 3-mos:
| | | (P = NS) | | | | | | G2: 5.0 (4.3) (P = NS) | | G1: 1.6 (1.4) (P = NR)
| | | Marital Status: | | | | | | G3: NA | | G2: 1.7 (1.5) (P = NR)
| | | Married or cohabitating: 63% | | | | | | (P = NR) | | G3: NA
| | | Divorced: 12% | | | | | | G1 better than G2 | | Diff between groups (P = NS)
| | | Widowed: 3% | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | Single: 22% | | | | | | 6-mos: | | 6-mos:
| | | Employed: | | | | | | G1: 3.7 (4.2) (P = NR) | | G1: 1.5 (1.4) (P = NR)
| | | 67% | | | | | | G2: 4.7 (4.0) (P = NR) | | G2: 1.8 (1.5) (P = NR)
| | | | | | | | | G3: NA | | G3: NA
| | | | | | | | | Diff between groups (P = NR) | | Diff between groups (P = NS)
| | | | | | | | | G1 better than G2 | | Diff between groups in change over time (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Abstinence/cessation rates: | | | BMI kg/m^2^, mean (SD): | BMI kg/m^2^, mean (SD):
| | | | | | | | | 12 wks (end of tx) | | | G1: 32.2 (6.4) | 12 wks (end of tx):
| | | | | | | | | G1: 50% | | | G2: 30.6 (6.6) | G1: 31.7 (6.1) (P = NR)
| | | | | | | | | G2: 43% | | | G3: 31.5 (6.6) | G2: 30.7 (6.6) (P = NR)
| | | | | | | | | G3: 8% | | | (P = NS) | G3: 31.9 (7.4) (P = NR)
| | | | | | | | | Diff between groups | | | | Diff between groups (P = NS)
| | | | | | | | | G1 vs G3 (P = 0.001) | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | G1 better than G3 | | | | 3-mos:
| | | | | | | | | G2 vs G3 (P = 0.008) | | | | G1: 30.8 (5.9) (P = NR)
| | | | | | | | | G2 better than G3 | | | | G2: 29.4 (5.6) (P = NR)
| | | | | | | | | 3-mos: | | | | G3: NA
| | | | | | | | | G1: 41% | | | | Diff between groups (P = NS)
| | | | | | | | | G2: 37% | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | G3: NA | | | | 6-mos:
| | | | | | | | | Diff between groups (P = NS) | | | | G1: 31.6 (6.2) (P = NR)
| | | | | | | | | 6-mos: | | | | G2: 30.4 (6.5) (P = NR)
| | | | | | | | | G1: 50% | | | | G3: NA
| | | | | | | | | G2: 40% | | | | Diff between groups 2(P = NS)
| | | | | | | | | G3: NA | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | Global EDE, mean (SD): | Global EDE, mean (SD):
| | | | | | | | G1: 3.6 (0.8) | 12 wks (end of tx)
| | | | | | | | G2: 3.7 (0.8) | G1: 2.1 (1.2) (P = 0.01)
| | | | | | | | G3: 3.6 (1.0) | G2: 2.7 (1.3) (P = 0.01)
| | | | | | | | (P = NS) | G3: 3.5 (0.8) (P = NR)
| | | | | | | | | Diff between groups
| | | | | | | | | G1 vs G3 (P = 0.001)
| | | | | | | | | G1 better than G3
| | | | | | | | | G2 vs G3 (P = 0.03)
| | | | | | | | | G2 better than G3
| | | | | | | | | G1 vs. G2 (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 3-mos:
| | | | | | | | | G1: 2.1 (1.3) (P = NS)
| | | | | | | | | G2: 2.6 (1.5) (P = NS)
| | | | | | | | | G3: NA
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 6-mos:
| | | | | | | | | G1: 2.4 (1.3) (P = NS)
| | | | | | | | | G2: 2.6 (1.5) (P = NS)
| | | | | | | | | G3: NA
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Restraint, mean (SD): | Restraint, mean (SD):
| | | | | | | | G1: 2.5 (1.4) | 12 wks (end of tx)
| | | | | | | | G2: 2.4 (1.5) | G1: 1.2 (1.3) (P = 0.01)
| | | | | | | | G3: 2.4 (1.4) | G2: 2.1 (1.4) (P = NS)
| | | | | | | | (P = NS) | G3: 2.6 (1.4) (P = NS)
| | | | | | | | | Diff between groups
| | | | | | | | | G1 vs G3 (P = 0.002)
| | | | | | | | | G1 better than G3
| | | | | | | | | G1 vs. G2 (P = 0.006)
| | | | | | | | | G1 better than G2
| | | | | | | | | G2 vs G3 (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | G1 > G2, G3
| | | | | | | | | 3-mos:
| | | | | | | | | G1: 1.0 (1.0) (P = NS)
| | | | | | | | | G2: 1.9 (1.6) (P = NS)
| | | | | | | | | G3: NA
| | | | | | | | | Diff between groups
| | | | | | | | | G1 vs G2 (P = 0.01)
| | | | | | | | | G1 better than G2
| | | | | | | | | 6-mos:
| | | | | | | | | G1: 1.3 (1.2) (P = NR)
| | | | | | | | | G2: 2.0 (1.6) (P = NR)
| | | | | | | | | G3: NA
| | | | | | | | | Diff between groups
| | | | | | | | | G1 vs G2 (P = NS)
| | | | | | | | Eating Concern, mean (SD): | Eating Concern, mean (SD):
| | | | | | | | G1: 3.4 (1.2) | 12 wks (end of tx)
| | | | | | | | G2: 3.5 (1.0) | G1: 1.4 (1.3) (P = NR)
| | | | | | | | G3: 3.6 (1.3) | G2: 2.0 (1.6) (P = NR)
| | | | | | | | (P = NS) | G3: 3.7 (1.1) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 3-mos:
| | | | | | | | | G1: 1.6 (1.5) (P = NR)
| | | | | | | | | G2: 2.2 (1.7) (P = NR)
| | | | | | | | | G3: NA
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 6-mos:
| | | | | | | | | G1: 1.8 (1.5) (P = NR)
| | | | | | | | | G2: 2.2 (1.6) (P = NR)
| | | | | | | | | G3: NA
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Shape Concern, mean (SD): | Shape Concern, mean (SD):
| | | | | | | | G1: 4.8 (1.0) | 12 wks (end of tx)
| | | | | | | | G2: 4.9 (0.8) | G1: 3.3 (1.5) (P = NR)
| | | | | | | | G3: 4.8 (1.3) | G2: 3.7 (1.6) (P = NR)
| | | | | | | | (P = NS) | G3: 4.6 (0.9) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 3-mos:
| | | | | | | | | G1: 3.3 (1.6) (P = NR)
| | | | | | | | | G2: 3.6 (1.8) (P = NR)
| | | | | | | | | G3: NA
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 6-mos:
| | | | | | | | | G1: 3.6 (1.6) (P = NR)
| | | | | | | | | G2: 3.7 (1.7) (P = NR)
| | | | | | | | | G3: NA
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Wt Concern, mean (SD): | Wt Concern, mean (SD):
| | | | | | | | G1: 3.8 (1.0) | 12 wks (end of tx)
| | | | | | | | G2: 4.0 (1.1) | G1: 2.5 (1.6) (P = NR)
| | | | | | | | G3: 3.6 (1.3) | G2: 3.1 (1.4) (P = NR)
| | | | | | | | (P = NS) | G3: 3.7 (1.1) (P = NR)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 3-mos:
| | | | | | | | | G1: 2.6 (1.5) (P = NR)
| | | | | | | | | G2: 2.8 (1.7) (P = NR)
| | | | | | | | | G3: NA
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 6-mos:
| | | | | | | | | G1: 2.8 (1.5) (P = NR)
| | | | | | | | | G2: 2.7 (1.7) (P = NR)
| | | | | | | | | G3: NA
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, mean (SD): | Inclusion: | For all participants, active tx 8 wks. Tx modified from manual-based CB intervention for BN. All participants given detailed manual that included psychoeducational materials and homework assignments. Included 14 one-hour sessions held twice wkly in the first 6 wks and wkly for final two wks. Each session included: psychoeducational info for the first 30 minutes and a discussion focusing on review of homework assignment for the second 30 min. | ANOVA and chi-square analyses used to compare groups on baseline demographic variables. A mixed effects model used to evaluate group, time and group x time interaction for the primary and secondary outcome variables. Chi-square analyses used to evaluate outcome based on SCID dx at post and FU assessments as well as on abstinence rates. | Score: | Objective Binge Episodes - based on Eating Behavior - IV (SD): | Objective binge episodes, mean (SD): | BDI, mean (SD) | BDI, mean (SD) | BMI kg/m^2^, mean (SD): | BMI, kg/m^2^, mean (SD)
Peterson et al., 2001 | To compare the short and long-term outcomes of three models of delivery of group CBT for patients with BED. | G1: Therapist led (TL) (N = 16) | Total sample: 42.9 yrs (10.1) | Met criteria for BED as listed in appendix for disorders warranting further investigation in the DSM IV using the SCID-patient version. | Groups not conducted simultaneously. G1: psychologist provided psychoeducational info and led group discussion and homework review. In G2: participants viewed videotape of psychologist delivering psychoeducational info followed by psychologist joining group and leading discussion in second 30 min. In G3: participants watched videotape and led their own discussion and review of homework, were given detailed list of discussion topics and group members facilitated discussion on rotating basis. The videotapes viewed by G2 and G3 were filed during the TL condition psychoeducational component. | | Fair | G1: 3.4 (1.7) | Post tx: | G1: 15.5 (9.9) | Post tx: | Total sample: 34.1 (7.04) | Post tx:
Setting: | | G2: Partial self-help (PSH) (N = 19) | G1: NR | Exclusion: | | | Intent to treat: | G2: 5.5 (6.7) | G1: 0.6 (1.4) (P = NR) | G2: 11.1 (9.1) | G1: 10.5 (9.9) | G1: 32.6 (8.2) | G1: 32.5 (8.9)
Eating disorders research clinic, University of Minnesota, Minneapolis, USA Outpatient | | G3: Structured self-help (SSH) (N = 16) | G2: NR | Taking any current psychoactive meds or involved in psychotherapy; substance abuse or dependence within 6 mos prior to enrollment in study, medical instability and acute risk of self-injury; met criteria for full or subthreshold BN, i.e., individuals who engaged in any compensatory behaviors in last six mos, including self- induced vomiting, abuse of diuretics or laxatives, fasting or excessive exercise | | | No | G3: 2.9 (2.2) | G2: 0.7 (1.5) (P = NR) | G3: 13.5 (9.5) | G2: 5.6 (3.6) | G2: 35.8 (6.0) | G2: 36.2 (5.5)
Enrollment period: | | Enrollment: | G3: NR | | | | Blinding: | (P = NR) | G3: 0.7 (2.2) (P = NR) | (P = NR) | G3: 9.0 (8.1) | G3: 33.6 (7.0) | G3: 32.4 (7.2)
NR | | - screened by phone for eligibility; - Potential participants attended orientation session and completed self-report questionnaires; - Participants scheduled for assessment session for structured interviews; - Participants assigned to one of four conditions with group size ranging from 4 to 10 (avg = 6); - Total of ten groups conducted at different time points; - Of 51 participants, 44 completed 8 wks of tx. | (P = NS) | | | | NA | | Diff over time (P < 0.0001) | | Diff over time: (P < 0.0001) | (P = NR) | Diff between groups (P = NS)
| | | Sex: | | | | Adverse events: | | Diff between groups (P = NS) | | Diff between groups (P = NS) | | Diff between groups in change over time (P = NS)
| | | Female: 100% | | | | None reported | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS) | | One mo FU:
| | | Race/ethnicity: | | | | Funding: | | One mo FU: | | One mo FU: | | G1: 31.5 (9.0)
| | | Caucasian: 96% | | | | McKnight Foundation; Minnesota Obesity Center; NIH; Neuropsychiatric Research Institute | | G1: 0.8 (1.1) (P = NR) | | G1: 6.6 (7.2) | | G2: 35.8 (5.7)
| | | African American: 2% | | | | | | G2: 1.1 (2.5) (P = NR) | | G2: 5.7 (4.6) | | G3: 33.3 (7.6)
| | | Native American: 2% | | | | | | G3: 0.9 (1.6) (P = NR) | | G3: 6.4 (7.3) | | Diff between groups (P = NS)
| | | G1: NR | | | | | | Diff over time (P < 0.0001) | | Diff over time (P < 0.0001) | | Diff between groups in change over time (P = NS)
| | | G2: NR | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS) | | Six mo FU:
| | | G3: NR | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS) | | G1: 30.2 (7.7)
| | | (P = NS) | | | | | | Six mo FU: | | Six mo FU: | | G2: 36.2 (6.5)
| | | | | | | | | G1: 0.7 (0.9) (P = NR) | | G1: 6.4 (7.0) | | G3: 32.0 (8.6)
| | | | | | | | | G2: 0.4 (0.7) (P = NR) | | G2: 6.3 (5.6) | | Diff between groups (P = NS)
| | | | | | | | | G3: 1.7 (3.9) (P = NR) | | G3: 6.9 (6.0) | | Diff between groups in change over time (P = NS)
| | | | | | | | | Diff over time (P < 0.0001) | | Diff over time (P < 0.0001) | | 12 mo FU:
| | | | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS) | | G1: 31.2 (7.9)
| | | | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS) | | G2: 35.8 (7.0)
| | | | | | | | | 12 mo FU: | | 12 mos FU: | | G3: 32.8 (7.4)
| | | | | | | | | G1: 0.5 (0.8) (P = NR) | | G1: 7.8 (8.1) | | Diff between groups (P = NS)
| | | | | | | | | G2: 1.1 (2.7) (P = NR) | | G2: 3.9 (3.7) | | Diff between groups in change over time (P = NS)
| | | | | | | | | G3: 1.0 (2.0) (P = NR) | | G3: 6.6 (7.4)
| | | | | | | | | Diff over time (P < 0.0001) | | Diff over time (P = 0.001)
| | | | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | | Total binge episodes, mean (SD): | Total binge episodes, mean (SD): | HDRS, mean (SD) | HDRS, mean (SD)
| | | | | | | | G1: 8.3 (3.1) | Post tx: | G1: 13.3 (7.3) | Post tx:
| | | | | | | | G2: 9.2 (6.7) | G1: 2.8 (3.2) | G2: 8.8 (6.9) | G1: 10.5 (7.3)
| | | | | | | | G3: 6.6 (2.2) | G2: 2.0 (3.4) | G3: 7.7 (5.9) | G2: 4.8 (3.3)
| | | | | | | | (P = NR) | G3: 2.4 (6.6) | (P = NR) | G3: 8.0 (6.4)
| | | | | | | | | Diff over time (P < 0.0001) | | Diff over time (baseline to post tx) (P = 0.03)
| | | | | | | | | Diff between groups (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
| | | | | | | | | One mo FU: | | One mo FU:
| | | | | | | | | G1: 4.4 (4.0) | | G1: 7.6 (3.7)
| | | | | | | | | G2: 3.7 (5.5) | | G2: 6.3 (4.9)
| | | | | | | | | G3: 1.2 (1.6) | | G3: 7.0 (7.0)
| | | | | | | | | Diff between groups (P = NS) | | Diff over time (baseline to 1 mo) (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS) | | Diff between groups (P = NS)
| | | | | | | | | Six mo FU: | | Diff between groups in change over time (P = NS)
| | | | | | | | | G1: 3.7 (3.9) | | Six mo FU:
| | | | | | | | | G2: 3.2 (3.0) | | G1: 6.5 (4.4)
| | | | | | | | | G3: 3.0 (3.6) | | G2: 7.7 (7.9)
| | | | | | | | | Diff between groups (P = NS) | | G3: 5.5 (4.6)
| | | | | | | | | Diff between groups in change over time (P = NS) | | Diff over time (baseline to 6 mos) (P = NS)
| | | | | | | | | 12 mo FU: | | Diff between groups (P = NS)
| | | | | | | | | G1: 3.5 (3.4) | | Diff between groups in change over time (P = NS)
| | | | | | | | | G2: 3.1 (4.8) | | 12 mos FU:
| | | | | | | | | G3: 3.3 (3.6) | | G1: 9.9 (8.6)
| | | | | | | | | Diff between groups (P = NS) | | G2: 3.8 (3.9)
| | | | | | | | | Diff between groups in change over time (P = NS) | | G3: 6.2 (4.7)
| | | | | | | | | | | Diff over time (baseline to 12 mos) (P = NS)
| | | | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Body Shape Questionnaire (BSQ) (SD) | Body Shape Questionnaire (BSQ), mean (SD)
| | | | | | | | G1: 140.6 (40.0) | G1: 108.4 (45.3)
| | | | | | | | G2: 141.1 (28.0) | G2: 113.7 (26.9)
| | | | | | | | G3: 127.7 (25.5) | G3: 110.2 (23.8)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | One mo FU:
| | | | | | | | | G1: 92.2 (28.7)
| | | | | | | | | G2: 112.9 (27.5)
| | | | | | | | | G3: 103.5 (28.6)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Six mo FU:
| | | | | | | | | G1: 94.0 (30.5)
| | | | | | | | | G2: 113.9 (23.0)
| | | | | | | | | G3: 103.7 (23.2)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 12 mo FU:
| | | | | | | | | G1: 91.1 (36.4)
| | | | | | | | | G2: 109.9 (33.0)
| | | | | | | | | G3: 105.2 (24.1)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Hours binged, mean (SD): | Hours binged, mean (SD):
| | | | | | | | G1: 9.0 (6.6) | Post tx:
| | | | | | | | G2: 13.5 (13.4) | G1: 2.6 (3.2)
| | | | | | | | G3: 10.0 (5.4) | G2: 2.1 (3.4)
| | | | | | | | (P = NR) | G3: 3.2 (8.9)
| | | | | | | | | Diff over time (P < 0.0001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | One mo FU:
| | | | | | | | | Hours Binged (SD):
| | | | | | | | | G1: 3.0 (2.4)
| | | | | | | | | G2: 3.8 (5.8)
| | | | | | | | | G3: 2.5 (3.8)
| | | | | | | | | Diff over time (P < 0.0001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Six mo FU:
| | | | | | | | | Hours binged (SD):
| | | | | | | | | G1: 2.3 (2.3)
| | | | | | | | | G2: 3.0 (2.5)
| | | | | | | | | G3: 3.6 (5.0)
| | | | | | | | | Diff over time (P < 0.0001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 12 mo FU:
| | | | | | | | | Hours binged (SD)
| | | | | | | | | G1: 2.4 (1.8)
| | | | | | | | | G2: 2.8 (4.6)
| | | | | | | | | G3: 4.5 (5.2)
| | | | | | | | | Diff over time (P < 0.0001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | Percent abstinent from objective binge for last wk: | Percent abstinent from Objective Binge for last wk:
| | | | | | | | G1: 0% | Post tx:
| | | | | | | | G2: 0% | G1: 78.6%
| | | | | | | | G3: 0% | G2: 75.0%
| | | | | | | | (P = NR) | G3: 90.0%
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | One mo FU:
| | | | | | | | | G1: 54.5%
| | | | | | | | | G2: 69.2%
| | | | | | | | | G3: 63.6%
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Six mo FU:
| | | | | | | | | G1: 55.6%
| | | | | | | | | G2: 70.0%
| | | | | | | | | G3: 75.0%
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 12 mo FU:
| | | | | | | | | G1: 66.7%
| | | | | | | | | G2: 84.6%
| | | | | | | | | G3: 75.0%
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | TFEQ Restraint, mean (SD): | TFEQ Restraint, mean (SD):
| | | | | | | | G1: 8.9 (4.8) | Post tx:
| | | | | | | | G2: 8.4 (4.2) | G1: 8.4 (3.5)
| | | | | | | | G3: 8.4 (4.4) | G2: 10.2 (4.3)
| | | | | | | | (P = NR) | G3: 8.4 (3.9)
| | | | | | | | | Diff over time (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | One mo FU:
| | | | | | | | | G1: 9.2 (3.7)
| | | | | | | | | G2: 10.2 (4.1)
| | | | | | | | | G3: 9.3 (4.0)
| | | | | | | | | Diff over time (baseline to 1 mo) (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Six mo FU:
| | | | | | | | | G1: 9.1 (4.6)
| | | | | | | | | G2: 10.1 (3.8)
| | | | | | | | | G3: 9.7 (5.1)
| | | | | | | | | Diff over time (baseline to 6 mos) (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 12 mo FU:
| | | | | | | | | G1: 8.2 (3.2)
| | | | | | | | | G2: 10.8 (5.0)
| | | | | | | | | G3: 10.2 (5.6)
| | | | | | | | | Diff over time (baseline to 1 mo) (P = NS)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | TFEQ Disinhibition (SD): | TFEQ Disinhibition (SD):
| | | | | | | | G1: 13.6 (2.0) | Post tx:
| | | | | | | | G2: 13.7 (2.3) | G1: 10.9 (2.7)
| | | | | | | | G3: 13.9 (1.7) | G2: 11.2 (2.4)
| | | | | | | | (P = NR) | G3: 10.9 (3.9)
| | | | | | | | | Diff over time (P < 0.0001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | One mo FU:
| | | | | | | | | G1: 9.7 (3.1)
| | | | | | | | | G2: 12.3 (2.2)
| | | | | | | | | G3: 10.8 (3.5)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Six mo FU:
| | | | | | | | | G1: 9.8 (2.6)
| | | | | | | | | G2: 12.4 (2.2)
| | | | | | | | | G3: 10.7 (3.4)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 12 mo FU:
| | | | | | | | | G1: 11.1 (2.6)
| | | | | | | | | G2: 10.0 (3.2)
| | | | | | | | | G3: 11.2 (3.6)
| | | | | | | | | Diff over time (P < 0.001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | TFEQ Hunger, mean (SD): | TFEQ Hunger, mean (SD):
| | | | | | | | G1: 10.9 (3.2) | Post tx:
| | | | | | | | G2: 8.7 (3.7) | G1: 7.3 (3.3)
| | | | | | | | G3: 9.7 (3.8) | G2: 6.9 (2.5)
| | | | | | | | (P = NR) | G3: 7.7 (4.7)
| | | | | | | | | Diff over time (P < 0.0001)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | One mo FU:)
| | | | | | | | | G1: 6.8 (3.7)
| | | | | | | | | G2: 8.3 (3.2)
| | | | | | | | | G3: 7.3 (5.1)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Six mo FU:
| | | | | | | | | G1: 7.4 (3.5)
| | | | | | | | | G2: 9.8 (3.3)
| | | | | | | | | G3: 7.1 (5.0)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | 12 mo FU:
| | | | | | | | | G1: 8.4 (3.7)
| | | | | | | | | G2: 8.4 (4.0)
| | | | | | | | | G3: 7.2 (5.2)
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Abstinent from objective binge episodes:
| | | | | | | | | Post tx:
| | | | | | | | | Data: NR
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | One mo FU:
| | | | | | | | | Data: NR
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Six mo FU:
| | | | | | | | | Data: NR
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 12 mo FU:
| | | | | | | | | Data: NR
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Abstinent from total binge episodes:
| | | | | | | | | Post tx:
| | | | | | | | | Data: NR
| | | | | | | | | Diff between groups (P = 0.05)
| | | | | | | | | G3 > G1 and G2
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | One mo:
| | | | | | | | | Data: NR
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | Six mo FU:
| | | | | | | | | Data: NR
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | | 12 mo FU:
| | | | | | | | | Data: NR
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Tx: manualized 8 wk-14 session CBT protocol adapted for BED. Subjects randomized in groups to waitlist, therapist-led, partial self-help, or structured self-help conditions. All groups met twice wkly for first six wks then wkly for final 2 wks. All 1 hr. sessions divided into two 30 minute parts: 1) reviewing psychoed material related to improving BED symptoms and 2) discussion and review of homework. In partial and structured self-help conditions, group members first watched videotape of therapist who was leading the therapist led group. In partial self-help condition, therapist led discussion for second part of the group while in structured self-help condition, group member on a rotating basis was responsible for leading discussion component for each session. | Regression analysis using a mixed effects linear regression model to est mean changes over time in the primary outcome variables of interest for the active tx conditions only; ANCOVAs for comparing between group diffs on secondary outcomes while controlling for baseline assessment; survival analysis for comparing retention rates of randomized subjects. | Score: | Objective binge-eating episodes/wk, mean (SD): | Mean objective binge-eating episodes/wk (SD): | HDRS (SD): | HDRS: | BMI, kg/m^2^: | BMI, kg/m^2^:
Peterson et al., 1998 | Compare the efficacy of a therapist-led versus self-guided group CBT interventions for BED | G1: Therapist-led (N = 16) | Total sample: 42.4 (10.2) | Met DSM IV criteria for BED | | | Fair | G1: 3.4 (1.7) | G1: 0.7 (1.3) | Data NR | Data NR | Data NR | Data NR
Setting: | | G2: Partial self-help (N = 19) | (P = NS) | Exclusion: | | | Intent to treat: | G2: 5.5 (6.5) | G2: 1.3 (3.4) | | Diff between groups (P = NR) | | Diff between groups (P = NR)
Single center; outpatient; University of Minnesota, Minneapolis, MN, USA | | G3: Structured self-help (N = 15) | Sex: | Receiving current psychotropic meds or psychotherapy; substance abuse or dependence within the past 6 mos; assessed to be medically unstable or at risk of self-injury; engaged in compensatory behaviors (e.g., self-induced vomiting, laxative or diuretic abuse, excessive exercising or fasting) within the last six mos | | | Yes | G3: 3.1 (2.1) | G3: 0.4 (1.1) | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = NS)
Enrollment period: | | G4: Waitlist control (N = 11) | Female: 100% | | | | Blinding: | G4: 3.5 (4.9) | G4: 4.7 (4.7)
NR | | Enrollment: | Race/ethnicity: | | | | Single | (P = NS) | Change over time (P < 0.0001)
| | - 238 screened who were recruited through newspaper ads; - 61 randomized (50 total to the active conditions); - 42 participants from the active conditions (G1, G2, and G3) remained at 8 wks, no sig diff in rate of retention | White: 96.5% | | | | Adverse events: | | Diff between groups (P = NR)
| | | (P = NS) | | | | NR | | Diff between groups in change over time (P < 0.001)
| | | Education: | | | | Funding: | | G1, G2, G3 better than G4
| | | College-educated: 51.7% | | | | McKnight Foundation grant; Minnesota Obesity Center | | Abstinence rate:
| | | (P = NS) | | | | | | G1: 68.8%
| | | Marital status: | | | | | | G2: 68.4%
| | | Married: 46.4% | | | | | | G3: 86.7%
| | | Divorced: 30.4% | | | | | | G4: 12.5%
| | | Never married: 19.6% | | | | | | Diff between groups G1 vs G2 vs G3 (P = NS)
| | | Other: 3.6% other | | | | | | Diff between G1 + G2 + G3 vs G4 (P = 0.004)
| | | (P = NS) | | | | | | Diff between groups in change over time (P = NR)
| | | | | | | | Total binge-eating episodes/wk, mean (SD): | Mean total binge-eating episodes/wk (SD):
| | | | | | | | G1: 7.7 (3.8) | G1: 3.3 (3.6)
| | | | | | | | G2: 8.2 (5.9) | G2: 2.7 (4.3)
| | | | | | | | G3: 6.8 (2.4) | G3: 1.8 (2.9)
| | | | | | | | G4: 5.7 (6.0) | G4: 6.6 (4.5)
| | | | | | | | (P = 0.008) | Change over time (P < 0.0001)
| | | | | | | | G1, G2 > G3 | Diff between groups (P =NR)
| | | | | | | | | Diff between groups in change over time (P = 0.002) G1, G2, G3 better than G4
| | | | | | | | | Abstinence rates for total binges:
| | | | | | | | | G1: 18.8%
| | | | | | | | | G2: 36.8%
| | | | | | | | | G3: 53.3%
| | | | | | | | | G4: 0%
| | | | | | | | | Diff between groups G4 vs G1, G2, G3 (P = 0.04): G4 worse than G1, G2, and G3
| | | | | | | | | Diff between G1, G2, and G3 (P = NS)
| | | | | | | | Hours spent binge-eating/wk, mean (SD): | Mean hours spent binge-eating/wk (SD):
| | | | | | | | G1: 9.0 (6.7) | G1: 4.2 (6.9)
| | | | | | | | G2: 13.4 (13.0) | G2: 3.2 (5.9)
| | | | | | | | G3: 9.8 (5.5) | G3: 2.3 (3.3)
| | | | | | | | G4: 8.3 (7.6) | G4: 9.6 (6.5)
| | | | | | | | (P = NS) | Change over time (P < 0.0001)
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.005) G1, G2, G3 better than G4
| | | | | | | | | Abstinence rate for hours spent bingeing:
| | | | | | | | | Data: NR
| | | | | | | | | Diff between groups G4 vs G1, G2, G3 (P = 0.04)
| | | | | | | | | G4 worse than G1, G2, and G3
| | | | | | | | | Diff between G1, G2, and G3 (P = NS)
| | | | | | | | BES: | BES:
| | | | | | | | NR | Data NR
| | | | | | | | | Diff between groups (P = NR
| | | | | | | | | Diff between groups in change over time (P = 0.024)
| | | | | | | | | G4 < (G1 = G2 = G3)
| | | | | | | | TFEQ: | TFEQ Restraint:
| | | | | | | | NR | Data NR
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | TFEQ Disinhibition:
| | | | | | | | | Data NR
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.003)
| | | | | | | | | G4 < (G1 = G2 = G3)
| | | | | | | | | TFEQ Hunger:
| | | | | | | | | Data NR
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.010)
| | | | | | | | | G4 < (G1 = G2 = G3)
| | | | | | | | BSQ: | BSQ:
| | | | | | | | NR | NR
| | | | | | | | | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)

Evidence Table 14. Other trials for binge eating disorder

| | | | | | | | Eating Related Measures | | Psychological/Psychiatric Measures | | Biomarkers
Study Description | Objective | Design | Patient Characteristics | Inclusion/Exclusion Criteria | Treatment | Statistical Methods | Quality | Baseline | Outcomes | Baseline | Outcomes | Baseline | Outcomes
Author, yr: | Research objective: | Groups: | Age, yrs, mean (SD): | Inclusion: | Participants randomized to one of two identical 24-wk tx programs or to a delayed tx control; active tx included exercise and calorie goal components. | Repeated measures ANOVAs used to assess diff between groups over time. | Score: | Binge days/28 days, mean (SD): | NR | BDI score, mean (SD): | NR | BMI, kg/m^2^, mean (SD): | NR
Levine, Marcus, and Moulton, 1996 | To examine the effects of an exercise intervention in the tx of obese women with BED. | G1: Active tx (N = 44) | G1: 36.3 (6.8) | NR | As preliminary analyses found no diff between identical active tx groups, they were combined for analyses. | Data reporting diff between groups based on exercise and abstinence, not reported in evidence table. | Poor | G1: 21.8 (11.8) | | G1: 18.3 (7.8) | | G1: 35.7 (4.6)
Setting: | | G2: Delayed control (N = 33) | G2: 37.0 (6.1) | Exclusion: | Assessments were conducted at baseline and post-tx; physical activity and binge eating status was assessed using the PEI and EDE respectively. | | Intent to treat: | G2: 20.7 (11.9) | | G2: 20.2 (7.8) | | G2: 38.2 (6.0)
NR | | Enrollment: | (P = NS) | NR | | | NR | (P = NS) | | (P = NS) | | (P = 0.05)
Enrollment period: | | - 77 recruited, randomized, and completed post-tx assessments | Sex: | | | | Blinding: | Exercise, days/wk, mean (SD): | Exercise, days/wk, mean (SD):
NR | | | Female: 100% | | | | NR | G1: 0.61 (1.4) | G1: 2.4 (2.4) (P = NR)
| | | Race/ethnicity: | | | | Adverse events: | G2: 0.62 (1.3) | G2: NR
| | | Caucasian | | | | NR | (P = NR) | Diff between groups (P = NR)
| | | G1: 88.6% | | | | Funding: | | Diff between groups in change over time (P = 0.003)
| | | G2: 78.8% | | | | NR | | G1 better than G2
| | | (P = NS) | | | | | Calorie expenditure, kcal/wk, mean (SD): | Calorie expenditure, kcal/wk, mean (SD):
| | | Education: | | | | | G1: 680.6 (823.0) | G1: 1103.2 (1111.1) (P = NR)
| | | Attended college: | | | | | G2: 610.9 (481.1) | G2: 610.9 (481.1) (P = NR)
| | | G1: 84.1% | | | | | (P = NR) | Diff between groups (P = NR)
| | | G2: 75.8% | | | | | | Diff between groups in change over time (P = NR)
| | | (P = NS) | | | | | | At post-tx, 82.4% tx group achieved abstinence.
| | | Married:
| | | G1: 56.8%
| | | G2: 60.6%
| | | (P= NS)
Author, yr: | Research objective: | Groups (N = 20): | Age, yrs, mean (SD): | Inclusion: | For G1 and G2, tx lasted approximately 6.5 wks; G1 received 7 sessions of Virtual Reality for Eating Disorders Modification (VREDIM) tx plus a low calorie diet (1200 cal/day) and physical training (30 minutes walking 2 times/wk); G2 received low cal diet, physical training, and psycho-nutritional, CBT-based group therapy, 3 times/wk. | Power analysis revealed low/medium power due to small sample and high SD. | Score: | BIAQ, total score, mean: | BIAQ, total score, mean: | STAI-State, total score, mean: | STAI-State, total score, mean: | Wt., kg, mean (SD): | NR
Riva et al., 2002 | To preliminarily test the efficacy of VR-based tx of body image attitudes and related constructs in women with BED. | G1: VR (N = NR) | G1: 30.50 (6.72) | Aged 18 to 45; met DSM IV research criteria for BED for a min of 6 mos | Assessments given at baseline and post-tx. | Accordingly, repeated and independent measures assessed using exact measures, non-parametric algorithms reliable with small, sparse or tied data. Specifically, the marginal homogeneity test was used. | Fair | G1: 33.20 | G1: 32.40 (P = NS) | G1: 47.80 | G1: 38.80 (P = 0.023) | G1: 120.06 (28.34)
Setting: | | G2: psycho-nutritional control (N = NR) | G2: 30.10 (6.95) | Exclusion: | | | Intent to treat: | G2: 31.00 | G2: 29.50 (P = NS) | G2: 39.20 | G2: 37.70 (P = NS) | G2: 109.82 (21.48)
Inpatient, wt-control tx program, Eating Disorders Unit of the Istituto Auxologico Italiano, Verbania Italy | | Enrollment: | (P = NR) | Taking antidepressant or any meds that might influence wt; hx of drug or alcohol abuse; current major psychiatric condition such as psychosis; hx of purging within previous 6 mos; BMI < 30 | | | NR | (P = NR) | Diff between groups (P = NR) | (P = NR) | Diff between groups (P = NR) | (P = NR)
Enrollment period: | | - 20 patients from ED program randomized, enrolled, and completed | Sex: | | | | Blinding: | | Diff between groups in change over time (P = NS) | | Diff between groups in change over time (P = 0.035)
NR | | | Female: 100% | | | | NR | | | | G1 better than G2
| | | Race/ethnicity: | | | | Adverse events: | BIAQ, Eating Restraint score, mean: | BIAQ, Eating Restraint, mean: | | | BMI, kg/m^2^, mean (SD): | NR
| | | NR | | | | No participants experienced stimulation sickness, often associated with VR. | G1: 3.00 | G1: 5.20 (P = NS) | | | G1: 44.07 (10.10)
| | | | | | | Funding: | G2: 4.40 | G2: 5.00 (P = NS) | | | G2: 42.35 (8.55)
| | | | | | | Commission of the European Communities (CEC) and the IST Programme (Project VESPY) | (P = NR) | Diff between groups (P = NR) | | | (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | CDRS, Real Body score, mean: | CDRS, Real Body score, mean:
| | | | | | | | G1: 7.80 | G1: 8.10 (P = NS)
| | | | | | | | G2: 8.40 | G2: 8.00 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | CDRS, Ideal Body score, mean: | CDRS Ideal Body score, mean:
| | | | | | | | G1: 4.40 | G1: 5.10 (P = 0.035)
| | | | | | | | G2: 4.40 | G2: 4.80 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | CDRS, Body Satisfaction Index, mean: | CDRS, Body Satisfaction Index, mean:
| | | | | | | | G1: 1.87 | G1: 1.66 (P = NS)
| | | | | | | | G2: 2.55 | G2: 2.29 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | BSS, total score, mean: | BSS, total score, mean:
| | | | | | | | G1: 51.30 | G1: 47.60 (P = NS)
| | | | | | | | G2: 57.20 | G2: 53.70 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | WELSQ, total score, mean: | WELSQ, total score, mean:
| | | | | | | | G1: 107.60 | G1: 146.80 (P = 0.050)
| | | | | | | | G2: 129.10 | G2: 130.30 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.005)
| | | | | | | | | G1 better than G2
| | | | | | | | FRS Real Body score, mean: | FRS Real Body score, mean:
| | | | | | | | G1: 6.90 | G1: 6.80 (P = NS)
| | | | | | | | G2: 6.80 | G2: 6.60 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | FRS Ideal Body score, mean: | FRS Ideal Body score, mean:
| | | | | | | | G1: 3.80 | G1: 3.90 (P = NS)
| | | | | | | | G2: 3.80 | G2: 3.80 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | FRS Body Satisfaction Index, mean: | FRS Body Satisfaction Index, mean:
| | | | | | | | G1: 1.87 | G1: 1.82 (P = NS)
| | | | | | | | G2: 2.35 | G2: 2.28 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | DIET total score, mean: | DIET total score, mean:
| | | | | | | | G1: 48.80 | G1: 39.03 (P = NS)
| | | | | | | | G2: 46.87 | G2: 45.90 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | DIET Positive Social score, mean: | DIET Positive Social score, mean:
| | | | | | | | G1: 54.00 | G1: 34.57 (P = 0.06)
| | | | | | | | G2: 47.57 | G2: 45.06 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | DIET Overeating score, mean: | DIET Overeating score, mean:
| | | | | | | | G1: 53.33 | G1: 31.50 (P = 0.30)
| | | | | | | | G2: 44.67 | G2: 44.00 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = 0.05)
| | | | | | | | | G1 better than G2
| | | | | | | | DIET Negative Emotions score, mean: | DIET Negative Emotions score, mean:
| | | | | | | | G1: 47.40 | G1: 37.60 (P = NS)
| | | | | | | | G2: 44.60 | G2: 47.20 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | DIET Resisting Temptations score, mean: | DIET Resisting Temptations score, mean:
| | | | | | | | G1: 40.00 | G1: 43.75 (P = NS)
| | | | | | | | G2: 38.75 | G2: 37.75 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over (P = NS)
| | | | | | | | DIET Exercise score, mean: | DIET Exercise score, mean:
| | | | | | | | G1: 46.00 | G1: 36.25 (P = NS)
| | | | | | | | G2: 57.00 | G2: 53.25 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | DIET Food Choice score, mean: | DIET Food Choice score, mean:
| | | | | | | | G1: 40.50 | G1: 43.00 (P = NS)
| | | | | | | | G2: 40.75 | G2: 41.75 (P = NS)
| | | | | | | | (P = NR) | Diff between groups (P = NR)
| | | | | | | | | Diff between groups in change over time (P = NS)
| | | | | | | | | Abstinence (No binge-eating in last 2 wks), mean:
| | | | | | | | | G1: 100%
| | | | | | | | | G2: 100%
| | | | | | | | | Diff between groups (P = NS)
| | | | | | | | | Diff between groups in change over time (P = NR)

Evidence Table 15. Anorexia nervosa outcomes

Study Description | Research Objective | Eligibility Criteria,Recruitment and Sample Size | Demographic and Other Characteristics | Quality | Study Methods and Analytic Strategy | Main Outcomes and Results
Authors, yr: | To identify predictors of outcome and to assess effects of available txs for AN or BN | Inclusion: | Mean Age (SD) | Score: | Study Methods | Descriptive Results
Ben-Tovim et al., 2001 | | 15 yrs old and older; living in Adelaide, South Australia; either making first contact with secondary or tertiary services for tx of ED or were recontacting such services after a tx break of at least 6 mos. | AN: 22.5 (6.9) | Good | Evaluation in person or by telephone annually. | AN:
Design: | | Exclusion: | BN: 23.8 (6.4) | Method of dx: | Statistical Methods | Dx at 5 yrs:
Case series | | None | Sex: | Dx made by treating clinician and confirmed by Flinders Symptom Score (FSS) interview. Dx was according to DSM III-R | Dependent variable: Total scores from M-R-H scales at 5 yrs | AN: 20 (21%)
Comparison Group: | | Recruitment: | Female: 100% | Funding | Multiple Regression | BN: 5 (5%)
No | | Agreement to participate was obtained from all identifiable specialist service providers in Adelaide, apart from one psychiatrist in individual practice. | Race/ethnicity: | Australian National Health and Medical Research Council, Flinders 2000, and the Centre for Applied Research in Mental Health | M-R-H Subscales: | EDNOS: 9 (9%)
Location: | | Sample size: | NR | | Subscale A: Dietary and eating patterns, body concern, and body wt | No ED: 56 (59%)
Adelaide, South Australia | | Fulfilled criteria: N = 235 | Wt, kg, Mean (SD): | | Subscale B: Menstrual pattern | Unknown: 2 (2%)
Yrs followed: | | Agreed to participate: N = 220 | AN: 44.8 (6.5) | | Subscale C: Mental State | Died: 3 (3%)
5 | | Baseline sample: | BN: 62.6 (10.8) | | Subscale D: Psychosexual state | M-R-H Outcomes:
| | AN: N = 95 | Height, m, Mean (SD): | | Subscale E: Work and Family Relations | Good (mean Score: 8 – 12): 32 (34%)
| | BN: N = 88 | AN: 1.65 (0.07) | | | Intermediate (score 4 - < 8): 51 (54%)
| | Reasons for loss to FU: | BN: 1.65 (0.06) | | | Poor (score 0 - < 4) 12 (13%)
| | Anorexia: 3 deaths, of which, 2 related to ED | BMI, Mean (SD): | | | BN
| | BN: 2 lost, reason NR | AN: 16.5 (1.9) | | | Dx at 5 yrs:
| | Analysis Sample Size at FU: | BN: 23.1 (3.9) | | | AN: 1 (1%)
| | AN: N = 92 | Duration of ED, yrs: | | | BN: 7 (8%)
| | BN: N = 86 | AN: 7.4 (7.0) | | | EDNOS: 11 (13%)
| | | BN: 6.4 (4.7) | | | No ED: 65 (74%)
| | | AN subtype at initial assessment: | | | Unknown: 4 (5%)
| | | Abstainers: 59% | | | Died: 0
| | | Binge-purgers: 41% | | | M-R-H Outcomes:
| | | | | | Good: 67 (76%)
| | | | | | Intermediate (score 4 - < 8): 17 (19%)
| | | | | | Poor (score 0 - < 4) 2 (2%)
| | | | | | Unknown: 2 (2%)
| | | | | | Multivariate Results
| | | | | | Predictors of higher M-R-H total mean score at 5 yrs:
| | | | | | AN:
| | | | | | Model 1
| | | | | | Age (P = 0.48)
| | | | | | M-R-H subscale A at baseline (P = 0.02) pos assoc.
| | | | | | M-R-H subscale B at baseline (P = 0.11)
| | | | | | M-R-H subscale C at baseline (P = 0.13)
| | | | | | M-R-H subscale D at baseline (P = 0.23)
| | | | | | M-R-H subscale E at baseline (P = 0.17)
| | | | | | Duration of Illness (yrs) (P = 0.18)
| | | | | | BMI at baseline (P = 0.08) pos assoc
| | | | | | Goodness of fit model (P < 0.0001), R^2^ = 0.0.33
| | | | | | Model 2
| | | | | | Disability adjustment scale, subscale 2 at baseline (P = 0.0006) neg assoc
| | | | | | Flinders Medical Centre Symptom Score at baseline (P = 0.03) neg assoc
| | | | | | Body Attitudes Questionnaire Subscales: Attractiveness at 6 mo:(P = 0.008) pos assoc
| | | | | | Change in salience of wt and shape over first 6 mos (P = 0.024) pos assoc
| | | | | | Goodness of fit model (P < 0.0001), R^2^ = 0.25
| | | | | Study Methods | Descriptive Results
| | | | | Evaluation in person or by telephone annually. | BN:
| | | | | Statistical Methods | Model 1
| | | | | Dependent variable: Total scores from M-R-H scales at 5 yrs | Age (P = 0.47)
| | | | | Multiple Regression | M-R-H subscale A at baseline (P = 0.01) neg assoc
| | | | | M-R-H Subscales: | M-R-H subscale B at baseline (P = 0.50)
| | | | | Subscale A: Dietary and eating patterns, body concern, and body wt | M-R-H subscale C at baseline (P = 0.16)
| | | | | Subscale B: Menstrual pattern | M-R-H subscale D at baseline (P = 0.28)
| | | | | Subscale C: Mental State | M-R-H subscale E at baseline (P = 0.28)
| | | | | Subscale D: Psychosexual state | Duration of Illness (yrs) (P = 0.11)
| | | | | Subscale E: Work and Family Relations | BMI at baseline (P = 0.27)
| | | | | | Goodness of fit model (P < 0.056); R^2^ = 0.085
| | | | | | Model 2
| | | | | | Disability adjustment scale, subscale 2 at recruitment (P = 0.009) neg assoc
| | | | | | Body Attitudes Questionnaire Subscales:
| | | | | | Feeling fat at recruitment (P = 0.02) neg assoc
| | | | | | Attractiveness at 6 mo (P = 0.001) pos assoc
| | | | | | Change in Zung Depression over first 6 mos (P = 0.0003) pos assoc
| | | | | | Goodness of fit model (P < 0.0001), R^2^ = 0.31
Authors, year: | SMR | Inclusion: | Age at tx start, mean (SD): | Score: | Study Methods: | AN Results:
Birmingham et al, 2005 | | DSM-III dx of an ED | Total: 26.1 (8.6) | Fair | Vital status assessed by searching Vital Statistics Agency of the BC Ministry of Health. For each death record, ICD-10 code recorded. | 17 pts died
Design: | | Exclusion: | AN: 24.7 (9.6) | Method of diagnosis: | Expected number of deaths obtained by applying age gender and year specific mortalities of general BC pop to cumulative person-yrs of the study cohort. | - suicide (n=7); - pneumonia (n=2); - hypoglycemia (n=2); - liver disease (n=2); - cancer (n=2); - alcohol poisoning (n=1); - subdural hemorrhage (n=1)
Case series | | None stated | Sex: | DSM III criteria for ED during clinical assessment (In discussion, authors state they use DSM III, DSM III-R, and DSM V criteria, but not mentioned in methods.) | Statistical Method: | SMR for AN = 10.5 (95% CI = 5.5–15.5)
Comparison Group: | | Recruitment: | Total, N (%): | Funding | SMR | BN Results:
No | | Referrals to adult tertiary care ED program in Vancouver, BC from 1981-2000 evaluated and given dx of ED using DSM criteria. | Females: 927 (97.2%) | NR | | 7 pts died
Location: | | Sample size: | Males: 27 (2.8%) | | | Cause of death NR
Vancouver, British Columbia, Canada | | (N = 954) | AN, N (%): | | | SMR for BN = 2.0 (95% CI = 0.5–3.5)
FU duration, years, Mean (SD): | | AN (N = 326) | Females: 312 (95.7%)
7.3 (4.9) for AN pts | | BN (N = 474) | Males: 14 (4.3%)
8.7 (5.2) for all patients | | Loss to FU: | Race/ethnicity:
| | None reported | NR
| | | Age at death, mean (SD):
| | | 36.3 (10.7)
| | | Time to death, years, mean (SD):
| | | 6.2 (4.8)
Authors, yr: | To explore what distinguished women who were fully recovered from women who recovered partially or who developed a chronic illness. | Inclusion: | Mean Age: | Score: | Study Methods | Descriptive Results
Bulik, Sullivan et al., 2000 | To examine diff between women who recovered fully and community controls to identify residual diff despite remission of the ED. | Cases: Newly dx via DSM III-R criteria for definite or “probable” AN, all determined meet lifetime DSM III-R criteria for AN; age 23–45 | Values NR: | Good | Cases: Hospital record of AN patients reviewed by 2 trained abstractors | Diff between groups (controlling for age):
Companion article: | To examine distinguishing characteristics of women who continued to suffer from an ED on avg 15 yrs after initial dx | Comparisons: Age matched to AN cases; age 23–45 | Diff between groups | Method of dx: | Interview using Diagnostic Interview for Genetic Studies and rated on the GAFS. Completed the EDI, TFEQ, Parental Bonding Instrument and the Temperament and Character Inventory | Current BMI, mean (SD):
Sullivan, Bulik et al., 1998 | | Exclusion: | G4 older than G1, G2, G3 (P = NR) | Criteria for DSM III or DSM IIIR determined through review of hospital records. | Statistical Analysis: | G1: 20.6 (2.1)
Design: | | Cases: None | Sex: | Funding | Chi-Square, ANOVA, ANCOVA to compare the 3 recovery groups and controls. Age was included as a covariate in all analyses. Critical P adopted to control for multiple comparisons (P < 0.01) | G2: 20.4 (1.4)
Case series | | Comparisons: subthreshold AN symptoms | Female: 100% | Canterbury Medical Research Foundation | | G3: 18.5 (2.6)
Comparison Group: | | Recruitment: | Race/ethnicity: | | | G4: 25.6 (6.5)
Yes | | Cases: Newly dx via DSM III-R criteria during inpatient, outpatient or assessment from 1981-1984 among those who received ED services at Princess Margaret Hospital, Christchurch, New Zealand, for definite or “probable” AN | NR | | | (P < 0.0001)
Location: | | Comparisons: randomly selected names obtained from 1993 Christchurch electoral record | Lowest past BMI, mean (SD): | | | G4 higher than all other groups
Christchurch, New Zealand | | Both: letter to invite participation; FU phone call; personal interview | G1: 14.8 (1.2) | | | Desired BMI, mean (SD):
Yrs followed: | | Initial Sample size: | G2: 14.8 (2.0) | | | G1: 20.1 (1.8)
12 yrs from tx referral | | Records reviewed: 239 | G3: 14.3 (1.4) | | | G2: 20.2 (1.3)
| | Potential AN: 89 | G4: NR | | | G3: 17.9 (2.5)
| | Potential Controls: 111 | (P = NS) | | | G4: 22.6 (2.6)
| | Reasons for loss to FU: | Highest past BMI, mean (SD): | | | (P < 0.001)
| | Death: 1 due to suicide while being treated for AN, 3 could not be located, 8 did not give consent, and 7 did not meet criteria for AN | G1: 23.1 (3.4) | | | G4 higher than other groups; G3 lower than G1 and G2
| | Analysis sample: | G2: 23.1 (2.9) | | | GAF Scale, mean (SD):
| | Cases = 70 | G3: 21.7 (2.4) | | | G1: 75.5 (11.2)
| | Comparisons = 98 | G4: 27.3 (6.7) | | | G2: 72.0 (15.1)
| | G1: Cases fully recovered (no current ED dx; > 85% IBW, no current bingeing and purging): N = 21 | (P < 0.001) | | | G3: 52.5 (12.2)
| | G2: Cases partially recovered (no current ED dx but reported current bingeing or purging or maintained a wt < 85% IBW): | G4 higher than other groups | | | G4: 80.3 (10.0)
| | N = 34 | Age at first diet, mean (SD): | | | (P < 0.001)
| | G3: Cases chronically ill (met criteria for ED at time of interview): | G1: 14.5 (2.7) | | | G3 lower functioning than other groups; G2 lower functioning than G4
| | N = 15 | G2: 16.6 (4.4) | | | TFEQ, Cognitive Restraint, mean (SD):
| | G4: Comparisons: | G3: 14.7 (3.3) | | | G1: 9.9 (5.9)
| | N = 98 | G4: 21.5 (6.6) | | | G2: 11.4 (5.3)
| | | (P < 0.001) | | | G3: 15.2 (5.3)
| | | G4 older than other groups | | | G4: 6.5 (4.8)
| | | Age of onset of AN, mean (SD): | | | (P < 0.001)
| | | G1: 16.4 (2.6) | | | G3 higher restraint than other groups; G4 lower restraint than G1 and G2
| | | G2: 17.4 (5.1) | | | TFEQ, Disinhibition, mean (SD):
| | | G3: 16.4 (3.5) | | | (P = NS)
| | | (P = NS) | | | TFEQ, Hunger, mean (SD):
| | | Lifetime BN | | | (P = NS)
| | | G1: 100% | | | EDI, Drive for Thinness, mean (SD):
| | | G2: 24% | | | G1: 4.5 (5.1)
| | | G3: 80% | | | G2: 4.7 (4.9)
| | | G4: 4% | | | G3: 11.8 (8.0)
| | | (P < 0.001) | | | G4: 3.1 (1.2)
| | | | | | Diff between groups (P < 0.0001)
| | | | | | G3 worse than other groups
| | | | | | EDI, Bulimia, mean (SD):
| | | | | | G1: 1.3 (1.9)
| | | | | | G2: 0.5 (1.0)
| | | | | | G3: 4.0 (4.4)
| | | | | | G4: 1.0 (1.6)
| | | | | | (P < 0.0001)
| | | | | | G3 worse than all other groups
| | | | | | EDI, Body Dissatisfaction, mean (SD):
| | | | | | G1: 8.4 (8.2)
| | | | | | G2: 9.0 (8.3)
| | | | | | G3: 15.6 (9.8)
| | | | | | G4: 11.5 (9.3)
| | | | | | Diff between groups (P = NS)
| | | | | | EDI, Perfectionism, mean (SD):
| | | | | | G1: 7.3 (4.5)
| | | | | | G2: 5.6 (4.9)
| | | | | | G3: 8.2 (4.4)
| | | | | | G4: 3.4 (3.3)
| | | | | | Diff between groups (P < 0.0001)
| | | | | | G4 had less perfectionism than all other groups
| | | | | | G1 had less perfectionism than G3
| | | | | | TCI, Harm Avoidance, mean (SD):
| | | | | | G1: 16.9 (6.8)
| | | | | | G2: 20.1 (6.9)
| | | | | | G3: 24.8 (9.6)
| | | | | | G4: 17.6 (7.8)
| | | | | | Diff between groups (P < 0.007)
| | | | | | G3 had higher harm avoidance than G1 or G4
| | | | | | TCI, Reward Dependence, mean (SD):
| | | | | | G1: 17.3 (3.9)
| | | | | | G2: 16.6 (3.4)
| | | | | | G3: 14.8 (3.9)
| | | | | | G4: 17.5 (3.4)
| | | | | | Diff between groups (P = NS)
| | | | | | TCI, Self-Directedness, mean (SD):
| | | | | | G1: 33.8 (8.1)
| | | | | | G2: 28.7 (8.6)
| | | | | | G3: 24.5 (9.1)
| | | | | | G4: 33.7 (7.2)
| | | | | | Diff between groups (P < 0.001)
| | | | | | G1 did better than G2 or G3
| | | | | | G4 did better than G2 or G3
| | | | | | PBI, Maternal Care, mean (SD):
| | | | | | G1: 22.2 (10.2)
| | | | | | G2: 23.8 (9.1)
| | | | | | G3: 15.8 (11.2)
| | | | | | G4: .26.0 (7.9)
| | | | | | Diff between groups (P < 0.002)
| | | | | | G3 lower score than G1, G2, G4
| | | | | | PBI, Maternal Protection, mean (SD):
| | | | | | G1: 18.1 (8.8)
| | | | | | G2: 15.1 (9.3)
| | | | | | G3: 14.2 (8.4)
| | | | | | G4: 13.2 (7.5)
| | | | | | Diff between groups (P = NS)
| | | | | | PBI, Maternal Protection, mean (SD):
| | | | | | G1: 18.1 (8.8)
| | | | | | G2: 15.1 (9.3)
| | | | | | G3: 14.2 (8.4)
| | | | | | G4: 13.2 (7.5)
| | | | | | Diff between groups (P = NS)
| | | | | | PBI, Paternal Care, mean (SD):
| | | | | | G1: 19.9 (8.5)
| | | | | | G2: 22.8 (10.0)
| | | | | | G3: 13.0 (13.1)
| | | | | | G4: 23.2 (9.2)
| | | | | | Diff between groups (P < 0.004)
| | | | | | G3 lower score than G1 or G4
| | | | | | PBI, Paternal Protection, mean (SD):
| | | | | | G1: 15.2 (8.0)
| | | | | | G2: 11.8 (5.7)
| | | | | | G3: 17.4 (10.6)
| | | | | | G4: 12.5 (7.5)
| | | | | | Diff between groups (P = NS)
Authors, yr: | 20 yr FU to determine the long-term mortality of AN in two cohorts | Inclusion: | Mean Age at FU (yrs): | Score: | Treatment Intervention: | Descriptive Findings:
Crisp et al., 1992 | | Both Crisps criteria and DSM III-R criteria for AN. | G1: 38.8 (6.7) | Fair | G1: Intensive individual and family therapy coupled with nutritional tx. | Mortality
Design: | | Exclusion: | G2: 40.9 (7.5) | Method of dx: | G2: Medical ward, outpt, inpatient (consisted of various tx's including: refeeding, nursing, meds, ECT, and/or modified insulin) | Death in 0 – 12 yrs, N (%):
Case series | | NR | Sex: | NR | Study Methods: | G1: 2 (2%)
Comparison Group: | | Recruitment: | Female: 100% | Funding | Record review | G2: 3 (5%)
No | | G1: Received tx at St George's Hospital in London between May 1968-December 1973 | Race/ethnicity: | NIMH | Statistical Methods: | Death in 12 – 24 yrs, N (%):
Location: | | G2: Registered on the Aberdeen Psychiatric Case Register in Aberdeen, Scotland between January 1965 and December 1973. | NR | | SMR, % | G1: 2 (2%)
England and Scotland | | Contact through telephone, physician, letter, friends and family, Social Services and Death Registry. | Mean age at onset of illness (yrs): | | | G2: 5 (8%)
Yrs followed: | | Sample size: | G1: 16.8 (3.8) | | | SMR:
G1: 21.8 (5.1) | | G1: N = 105 | G2: 19.1 (5.3) | | | G1: 1.36 times more likely to die than women of the same age in England and Wales during 1973 - 1989
G2: 22.1 (4.9) | | G2: N = 63 | Diff between groups (P < 0.01) | | | G2: 4.71 times more likely to die than women of the same age in Scotland in 1973 - 1979.
| | Reasons for loss to FU: | Duration of illness (yrs): | | | Diff between groups (P = NS)
| | G1: Died = 4 (2 from complications of AN, 1 from suicide, and 1 other; | G1: 3.7 (4.1) | | | Causes of Death:
| | Untraced = 4 | G2: 2.0 (2.4) | | | Anorexia, N:
| | G2: Died = 8 (3 complications of AN, 4 suicides, 1 other); Untraced: 2 | Diff between groups (P < 0.01) | | | G1: 2 (2%)
| | | | | | G2: 3 (5%)
| | | | | | Suicide, N:
| | | | | | G1: 1 (1%)
| | | | | | G2: 4 (6%)
| | | | | | Other, N:
| | | | | | G1: 1 (1%) cancer
| | | | | | G2: 1 (2%) cancer
Authors, yr: | To assess the relationships among MMPI clinical scales over a 10-yr period in a sample of AN patients | Inclusion: | Mean Age at Admission for sample of N = 76, yrs (SD): | Score: | Study Methods | Descriptive Findings
Dancyger et al., 1997 | | Initial inclusion criteria involved modified Feighner et al. 1972, and subsequently covered DSM III-R and DSM IV for AN. | 19.29 (4.97) | Fair | Participants administered the MMPI at admission, at discharge and at 10-yr FU. During FU interview, participants' outcome assessed via M-R score using last 6-mos prior to the FU as window for evaluation of clinical status. | Outcome status at 10-yr FU:
Design: | | Exclusion: | Mean age of FU sample: | Method of dx: | Outcome categories: | Recovered: N = 16
Case series | | NR | NR | Independent Clinician Dx | Poor: < 85% of IBW with amenorrhea or frequent bingeing and purging (i.e., met criteria for BN, AN, or both) | Good: N = 7
Comparison Group: | | Recruitment: | Sex: | At intake: use of Feighner et al., 1972, DSM III-R and DSM IV criteria. Outcome classification was determined at FU using the M-R scale. | Intermediate: intermittently at < 85% IBW, had some disturbed menses or some bingeing and purging behavior (i.e., subthreshold AN, BN, or EDNOS) | Intermediate: N = 11
No | | All participants at intake were part of a larger collaborative study and were admitted into a 35-day hospital inpatient tx for AN, 40 from U of Iowa and 36 from U of Minnesota | Female: 100% | Funding | Good: > 85% IBW, normal menses but binged and purged < once/mo | Poor: N = 18
Location: | | Sample size: | Race/ethnicity: | NR | Recovered: above the 85% IBW cutoff, had no menstrual disturbances, reported no bingeing or purging behavior, and free from any other eating or body image disturbance | Mean changes in MMPI scale scores from Admission to Discharge to FU
Minnesota and Iowa | | Initial sample: | NR | | Raw MMPI scale scores were K-corrected and converted to T-scores (mean = 50, SD = 10). Clinical elevation is defined as a T-score of 70 or higher | Lying (P = NS)
Yrs followed: | | N = 76 | | | Statistical Analyses | Frequency (P = NS)
10 | | Reasons for loss to FU: | | | Repeated measures MANOVAs used to detect diff between outcome status groups' MMPI scale scores at the three assessment time points. MANOVA's were followed by pairwise comparisons with alpha level corrected using Bonferroni procedure | Defensiveness (P = NS)
| | Excluded because of incomplete data: N = 7 | | | Correlational analyses performed to assess relationships between MMPI scale scores at the three time points | Hypochondriasis (1) (P < 0.05) Admission > Discharge and FU
| | Died: N = 5 | | | Individual configural analyses of MMPI conducted to determine MMPI configurations at the three assessment points | Depression (2) (P < 0.05) Admission > Discharge and FU
| | Refused participation: N = 9 | | | Backward elimination stepwise multiple regression models with MMPI scales as predictors of outcome status at FU were conducted | Hysteria (3) (P < 0.05) Discharge < Admission and FU
| | Did not complete MMPI: N = 3 | | | | Psychopathic Deviate (4) (P = NS)
| | Analysis sample | | | | Masculinity-Femininity (5) (P = NS)
| | N = 52 | | | | Paranoia (6) (P = NS)
| | | | | | Psychasthenia (7) (P < 0.05) (Admission > Discharge and FU)
| | | | | | Schizophrenia (8) (P = NS)
| | | | | | Hypomania (9) (P = NS)
| | | | | | Social Introversion (10) (P = NS)
| | | | | | Configural Analysis of MMPI at FU
| | | | | | Impulsive/characterological: 9
| | | | | | Normal/Depressive: 32/3
| | | | | | Other: 8
| | | | | | Percentage of Subjects with each Single Peak MMPI Score at FU
| | | | | | Depression (2): 14%
| | | | | | Hysteria (3): 18%
| | | | | | Psychopathic Deviate (4): 17%
| | | | | | Paranoia (6): 13%
| | | | | | Psychasthenia (7): 12%
| | | | | | Hypomania (9): 7%
| | | | | | Social Introversion (10): 8%
| | | | | | Percentage of Outcome Groups with at least one MMPI Clinical Elevation at FU
| | | | | | Poor: 67%
| | | | | | Intermediate: 45%
| | | | | | Good: 14%
| | | | | | Recovered: 12%
| | | | | | Correlations Between MMPI Scale Scores at Discharge and FU
| | | | | | Hypochondriasis: r = 0.32 (P = NS)
| | | | | | Depression: r = 0.56 (P < 0.003)
| | | | | | Hysteria: r = 0.37 (P < 0.05)
| | | | | | Psychopathic Deviate: r = 0.39 (P < 0.05)
| | | | | | Masculinity/Femininity: r = 0.17 (P = NS)
| | | | | | Paranoia: r = 0.41 (P < 0.05)
| | | | | | Psychasthenia: r = 0.52 (P < 0.003)
| | | | | | Schizophrenia: r = 0.37 (P < 0.05)
| | | | | | Hypomania: r = 0.31 (P = NS)
| | | | | | Social Introversion: r = 0.68 (P < 0.003)
| | | | | | Diff in MMPI Scale Scores at FU By Outcome Groups (Recovered versus Poor)
| | | | | | Lying (P = NS)
| | | | | | Frequency (P = NS)
| | | | | | Defensiveness (P = NS)
| | | | | | Hypochondriasis: (P < 0.05) (Recovered < Poor)
| | | | | | Depression: (P < 0.05) (Recovered < Poor)
| | | | | | Hysteria: (P < 0.05) (Recovered < Poor)
| | | | | | Psychopathic Deviate: (P < 0.05) (Recovered < Poor)
| | | | | | Masculinity-Femininity (P = NS)
| | | | | | Paranoia (P = NS)
| | | | | | Psychasthenia: (P < 0.05) (Recovered < Poor)
| | | | | | Schizophrenia: (P < 0.05) (Recovered < Poor)
| | | | | | Hypomania (P = NS)
| | | | | | Social Introversion (P = NS)
| | | | | | Change in Overall MMPI score admission to FU
| | | | | | (P < 0.001) Recovered greater decline than poor
| | | | | | Multivariate Result
| | | | | | Predictors of outcome at 10 yr FU using backward-elimination stepwise multiple regression. (P redicted 25% of the variance)
| | | | | | Hypochondriasis (scale 1):higher scores associated with poorer outcome
| | | | | | Paranoia (scale 6): higher scores associated with poorer outcome.
| | | | | | Psychopathic deviate: higher scores associated with poorer outcome
Authors, yr: | To determine if long term outcomes of AN patients are associated with higher recovery (> 50%) and mortality rates (>5%) and lower rates of chronicity and poor outcome; whether inclusion of psychiatric and medical comorbidity and social adaptation influence results compared with mere evaluation of the physical status using M-R criteria and which predictors remain sig over time | Inclusion: | Mean Age | Score: | Study Methods: | Descriptive Results
Deter and Herzog, 1994 | | Fulfilled dx criteria for AN according to Feighner et al., and on retrospective analysis, the DSM III-R criteria. | 32.5 (6.1) | Fair | Interview using ANSS, physical examination and medical record review | Wt, kg, mean (SD):
Companion article: | | Exclusion: | Sex: | Method of dx: | Statistical Methods | At first presentation: 36.3 (6.2)
Herzog, Schellberg, and Deter, 1997 | | Somatic diseases at first presentation which did not have any direct etiologic relation to AN; Male | Female: 100% | Feighner et al., and on retrospective analysis DSM III-R | ANOVA, MANOVA | FU: 53.1 (9.5)
Design: | | Recruitment: | Race/ethnicity: | Funding | T test or Student-Newman-Keuls | Diff over time (P < 0.0001)
Case series | | All AN patients admitted and treated consecutively between 1/71 and 10/80 at University Medical Clinic of Heidelberg. | NR | German Ministry for Research and Technology | Spearman correlations and factor analyses | Wt, %ABW, 37:
Comparison Group: | | Sample size: | | | Step-wise multiple regression | At first presentation: 65.2 (9.9)
No | | Initial Sample | | | Comparisons: ANOVA and Student-Newman-Keul's | FU: 88.4 (14.8)
Location: | | N = 84 | | | Outcome categories | Diff over time (P < 0.0001)
Germany | | Restricting AN: N = 29 (35%) | | | Permanent recovery: rated as good according to M-R scale and remained so | BMI
Yrs followed: | | Mild purging: N = 19 (23%) | | | Relapse: rated as good according to M-R scale but afterwards assessed as intermediate or poor | At first presentation: 13.3 (2.0)
MeAN: 11.8 yrs (Range: 9–19) | | Severe purging: N = 36 (43%) | | | Persistent ED: not defined | FU: 19.6 (3.3)
| | Reasons for loss to FU: | | | | Diff over time (P < 0.0001)
| | Death: N = 9. Of these, suicide: N = 2 | | | | Amenorrhea, %:
| | Analysis sample: | | | | At first presentation: 100%
| | N = 75 | | | | FU: 14.9%
| | | | | | Diff over time (P < 0.0001)
| | | | | | ED Morbidity at FU:
| | | | | | BN: 10/74 (14%)
| | | | | | Mild bulimic symptoms: 12 (16%)
| | | | | | Laxative abuse without binge eating: 8%
| | | | | | ANSS Avg Outcome Score, mean (SD)
| | | | | | At first presentation: 20.1 (3.9)
| | | | | | FU: 8.7 (5.3)
| | | | | | Diff over time (P < 0.0001)
| | | | | | ANSS Pathological findings (%), mean (SD)
| | | | | | At first presentation: 67.2 (12.3)
| | | | | | FU: 29.6 (17.4)
| | | | | | Diff over time (P < 0.0001)
| | | | | | ANSS Somatic symptoms, mean (SD)
| | | | | | At first presentation: 61.7 (15.9)
| | | | | | FU: 23.5 (18.6)
| | | | | | Diff over time (P < 0.0001)
| | | | | | M-R Scale, Avg Outcome Score, mean (SD)
| | | | | | At first presentation: 2.4 (1.4)
| | | | | | FU: 8.6 (2.8)
| | | | | | Diff over time (P < 0.0001)
| | | | | | M-R Scale, Menstrual function, mean (SD)
| | | | | | At first presentation: 0.5 (0.3)
| | | | | | FU: 10.1 (3.9)
| | | | | | Diff over time (P < 0.0001)
| | | | | | M-R Scale, Mental state, mean (SD)
| | | | | | At first presentation: 4.0 (0.8)
| | | | | | FU: 8.1 (2.5)
| | | | | | Diff over time (P < 0.0001)
| | | | | | M-R Global Outcome at FU (modified by Eckert, 1990):
| | | | | | Good: 53.6%
| | | | | | Intermediate: 25.0%
| | | | | | Poor:10.7%
| | | | | | Deceased: 10.7%
| | | | | | Psychiatric Morbidity, DSM III-R at FU:
| | | | | | Phobic Disorders: 12.2%
| | | | | | Substance Abuse: 13.5%
| | | | | | Major Depression: 8.1%
| | | | | | Personality Disorders: 17.6%
| | | | | | Chronic Psychosis: 5.4%
| | | | | | OCD: 8.1%
| | | | | | Psychiatric morbidity: 32.4%
| | | | | | Somatic Morbidity at FU: 32%
| | | | | | Healthy according to M-R scale criteria:
| | | | | | 2 yr FU: 5%
| | | | | | 4 yr FU: 23%
| | | | | | 6 yr FU: 37%
| | | | | | 9 yr FU: 43%
| | | | | | 11 yr FU: 52%
| | | | | | AN dx:
| | | | | | 2 yr FU: 67%
| | | | | | 4 yr FU: 40%
| | | | | | 6 yr FU: 23%
| | | | | | 9 yr FU: 17%
| | | | | | Diff between recovered patients (N = 36)
| | | | | | Persistent eating disorders/dead (N = 31)
| | | | | | Relapsing patients (N = 17)
| | | | | | Age at onset of illness, yrs, meAN:
| | | | | | Permanent recovery: 16.8
| | | | | | Persistent: 18.8
| | | | | | Relapsing: 18.1
| | | | | | Diff between groups (P = NR)
| | | | | | Age at first presentation, yrs, meAN:
| | | | | | Permanent recovery: 19.3
| | | | | | Persistent: 23.3
| | | | | | Relapsing: 18.9
| | | | | | Diff between groups (P = 0.007)
| | | | | | Permanent recovery younger than Persistent
| | | | | | Persistent older than Relapsing
| | | | | | Duration of illness prior to first presentation, yrs, meAN:
| | | | | | Permanent recovery: 2.4
| | | | | | Persistent: 4.5
| | | | | | Relapsing: 0.8
| | | | | | Diff between groups (P = 0.005)
| | | | | | Persistent longer duration than Relapsing
| | | | | | Somatic symptoms (%):
| | | | | | Permanent recovery: 57.2
| | | | | | Persistent: 67.5
| | | | | | Relapsing: 62.6
| | | | | | Diff between groups (P = 0.03)
| | | | | | Recovery less symptoms than Persistent
| | | | | | Laxatives at first presentation (rating 0 – 4):
| | | | | | Permanent recovery: 1.1
| | | | | | Persistent: 2.1
| | | | | | Relapsing: 1.6
| | | | | | Diff between groups (P = 0.04)
| | | | | | Recovery did better than Persistent
| | | | | | Vomiting at first presentation (rating 0 – 4):
| | | | | | Permanent recovery: 1.6
| | | | | | Persistent: 2.1
| | | | | | Relapsing: 0.5
| | | | | | Diff between groups (P = 0.03)
| | | | | | Persistent higher rating than Relapsing
Authors, yr: | In a long-term FU of AN patients, develop simple, clinically interpretable data that can be helpful in clinical decision-making | Inclusion: | Mean Age at Intake, mean (SD): | Score: | Study Methods: | Descriptive Results
Deter et al., 2005 | | - Met criteria for AN according to Feighner et al.; DSM III-R | 20.7 (4.1) | Fair | Predictor variables, including medical data, collected at inpatient admission, interviews and diagnostics with physicians, psychotherapists. | Univariate Analysis:
Design: | | Exclusion: | Avg length of illness before inclusion: | Method of dx: | Annual collections of MR outcome categories by general practitioner or information provided by health insurance agencies. | Factors associated with good somatic M-R outcome at 4 yrs (P values NR):
Prospective and retrospective | | - Male; additional somatic diseases not related to AN | 2.7 (3.9) | Feighner criteria and DSM III-R in retrospective analysis. Method of dx NR | FU assessments made an avg of 3.6 yrs and again 11.8 yrs after first admission. | Early onset of disease
Comparison Group: | | Recruitment: | Mean relative ABW at first admission: | Funding | Isolated predictors known from the literature over longer time periods and carried out a separate investigation of predictors of the Heidelberg-Mannheim study over a mean period of 12 yrs (range 9–19yrs). | No strong vomiting or laxative abuse
No | | - All AN inpatients who were treated consecutively from 1/1/1971 and 10/31/1980 at the Department of General Clinical and Psychosomatic Medicine, University of Heidelberg Medical School. | 65.2% (9.9) | NR | Calculated separate hierarchic regression analyses on the bases of the course of the M-R categories for four individually recorded areas: anamnestic, psychological, somatic and social data sets. | No vomiting
Location: | | Sample size: | BMI (SD): | | Outcomes | Positive M-R eating habits and psychological status scales at baseline
Heidelberg, Germany | | Initial sample: | 13.3 (2.0) | | Global Score: Sum of 6 predictor variables (age of onset, purging, albumin, GOT, ANSS psychic findings, ANSS social findings) | Positive ANSS social status score
Yrs followed: | | N = 84 | Sex: | | Statistical Methods: | No sexual partner
11.8 (2.4) | | Reasons for loss to FU: | Female; 100% | | Univariate analysis to predict M-R outcome categories at 4, 8, and 12 yrs; and the Deter-Herzog criteria after 12 yrs (U test calculated for quantitative predictors and the Chi-square for dichotomized variables). | No amenorrhea
Range: 9–19 | | Death: 9 due to ED (electrolyte disturbances) and secondary consequences of chronic AN such as infections or renal failure; 2 due to suicide. | Race/ethnicity: | | Multivariate testing to obtain most sig predictors. | Factors associated with good somatic M-R outcome at 8 yrs (P values NR):
| | - Not available for examination: N = 5 | NR | | Survival analyses to assess “survival rate.” Similarity or diff between strata checked by the log-rank test. | Younger age overall
| | Analysis Sample size: | Social Class: | | | Early onset of disease
| | N = 70 | Lower: 45.2% | | | Lower strong vomiting or laxative abuse
| | | Middle: 48.8% | | | Low M-R values for eating habits and social activities at baseline
| | | Upper: 6.0% | | | Low ANSS values for low occupational integration, body image disturbance, self-destructive tendencies, pathological findings
| | | | | | Higher social activities
| | | | | | Potassium and albumin levels
| | | | | | Factors associated with good somatic M-R outcome at12 yrs (P values NR):
| | | | | | Positive ANSS psychic and social scale scores
| | | | | | Younger age overall
| | | | | | Earlier onset of disease
| | | | | | Good M-R ratings of psycho-sexual integration, personal contacts, eating habits, abundance of family, social activities
| | | | | | Low ANSS values for low occupational integration, low understanding of family of origin, % pathological findings
| | | | | | Potassium level
| | | | | | Albumin level
| | | | | | Low addictive tendencies
| | | | | | Predictor of favorable psychosocial and somatic Deter-Herzog course at 12 yrs (some P values NR):
| | | | | | Good social integration (P = 0.05)
| | | | | | No severe psychic symptoms (P = 0.04)
| | | | | | Earlier onset of disease
| | | | | | Lower strong vomiting or laxative abuse
| | | | | | Low M-R values for eating habits at baseline
| | | | | | Potassium level
| | | | | | Glucose level
| | | | | | Albumin level
| | | | | | Multivariate Analysis:
| | | | | | Predictors of Deter-Herzog criteria at 12 yrs:
| | | | | | Serum albumin level (P = 0.01)
| | | | | | ANSS social integration score (P = 0.03)
| | | | | | Survival Analysis:
| | | | | | Predictors of Persistence (“survival) of AN symptoms at 12 yrs (N = 81):
| | | | | | Age of onset and purging (P = 0.001)
| | | | | | - Poor outcome (high AN symptoms) = disease onset > 18 yrs; - Moderate outcome = onset < 18 yrs + purging; - Good outcome = onset < 18 yrs, no purging
| | | | | | Albumin and glutamic-oxalo acetic transaminase (GOT) levels (P = 0.013)
| | | | | | - Poor outcome = low albumin level; - Moderate outcome = normal albumin, high GOT; - Good outcome = normal albumin and GOT
| | | | | | Global prognosis score (P = 0.019)
| | | | | | - Poor outcome = high global score; - Good outcome = low global score
Authors, yr: | To describe the clinical course and outcome of the core symptoms of AN who participated 10 yrs previously in a collaborative hospital tx study. | Inclusion: | Mean Age (SD) (range): | Score: | Study Methods | Descriptive Results:
Eckert et al., 1995 | | Feighner's and DSM III-R criteria for AN. | 20.0 (5.2) (12 – 36) | Fair | Where possible, subjects and their parents were interviewed personally by two well-trained research assistants either in their homes or at the hospital. | Deaths:
Design: | | Exclusion: | Sex: | Method of dx: | Outcomes (based upon clinical status for the 1 yr interval preceding FU): | 5 (crude mortality rate: 6.6%)
Case series | | NR | Female: 100% | Structured Clinical Interview: | Recovered: Wt within 15 % of ideal wt, cyclical menses, and no sig disturbance in eating or wt control behavior or body image disturbance. | All complications of AN (no suicides) all showed early signs of poor outcome (very low wt at hospitalization and time of death, older age of onset, disturbance in wt control behavior.
Comparison Group: | | Recruitment: | Race/ethnicity: | Diagnostic Interview Schedule | Good: Wt within 15% of IBW, cyclical menses, and the presence of sig eating or wt control behavior (e.g., binge eating, vomiting, laxative diuretic abuse, diet pill use, undue dieting) or sig body image disturbance. | Expected mortality rate:
No | | 76 of the 105 patients who participated in a 35 day hospital tx study which compared the efficacy of a behavior therapy program with a cyproheptadine regimen. 76 is the total enrollment of all patients from 2 of the three collaborative referral hospitals participating in the tx study. | Caucasian: 100% | Funding | Intermediate: Wt only intermittently within 15% of IBW and/or presence of menstrual disturbances. | 0.39
Location: | | Sample size: | Marital Status: | NIMH | Poor: Wt has remained below 15% of IBW and menstruation has been absent or virtually absent. | Ratio of observed to expected deaths:
USA | | N = 76 | Single: 62 (82%) | | Statistical Methods | 12:82
Yrs followed: | | | Married/Divorced: 14 (18%) | | Frequencies and chi-squares | Diff (P < 0.05); study population had a sigly increased mortality.
10 | | | Duration of illness, yrs, mean (SD) (range): | | | Various sociodemographic characteristics:
MeAN: | | | 3.0 (3.2) (0.3 – 19) | | | Compared to expected age-sex scales from the US, the study population had: more subjects living alone, not in a conjugal relationship, lived more often with non-relatives, had never been married, and were more often childless or had fewer children (P < 0.001) and more induced abortions (P < 0.01).
9.6 (0.8) (range: 8.5 – 10.5) | | | Avg wt below normal, %, mean (SD) (range): | | | Menses:
| | | 31.1 (8.8) (9.8 – 47.4) | | | First onset or return of menses during FU: 60 (85%); 49 (69%) spontaneously and 11 (16%) with meds.
| | | Binge-eating: | | | Of spontaneous remissions:
| | | 36 (47%) | | | Within first yr: 35%
| | | Vomiting: | | | Within 5 yrs: 85%
| | | 29 (38%) | | | Within last 5 yrs of study: 15%
| | | Laxative abuse: | | | Mean % of IBW when regained menses spontaneously: 92.0% (11.4) (range: 70.9 – 138.3%); Wt was achieved and maintained at 12.4 (14.0) (range: 1 – 72) mos before menses returned.
| | | 31 (41%) | | | Regularity of menstrual pattern in last 6 mos preceding FU, N (%):
| | | Previous hospitalizations for AN: | | | Regular: 34 (48%)
| | | 37 (49%) | | | Somewhat irregular (variation 4 – 10 days): 6 (18%)
| | | Previous outpt therapy for AN: | | | Very irregular (variation > 10 days): 6 (8%)
| | | 36 (47%) | | | Skipped or rare menses: 7 (19%)
| | | Age at FU, Median (range): | | | Never menstruated: 11 (15%)
| | | 28 (21 – 47) | | | Wt at FU:
| | | | | | Below normal wt (BMI < 17.5 and < 85% below avg wt): 16 (22.5%)
| | | | | | Normal wt (BMI: 17.5 – 23.5 and between 85 – 115% of avg wt): 52 (73.2%)
| | | | | | Mild obesity (BMI 23.6 – 26.5 and between 116 – 125% of avg wt): 2 (2.8%)
| | | | | | Severe obesity (BMI > 26.5 and > 125% of avg wt): 1 (1.4%)
| | | | | | Relapse (first wt loss below normal at any time after the index hospitalization):
| | | | | | n = 34 during the first 8 yrs of FU
| | | | | | Probability of relapse:
| | | | | | 0.37; 24 (37%) of all 66 subjects who attained normal wt during FU relapsed before they had been normal wt for 1 yr. If they maintained their wt for at least 1 yr, their chance of continuing to remain in normal wt improved considerably.
| | | | | | Correlates of wt at FU per Anorectic Outcome Scale (Lower wt was associated with):
| | | | | | Greater food faddiness (P < 0.01)
| | | | | | Greater laxative abuse (P < 0.01)
| | | | | | Other wt loss behavior (P < 0.01)
| | | | | | Greater body image disturbance (P < 0.01)
| | | | | | Greater fear of becoming fat (P < 0.05)
| | | | | | Greater disturbed sexual adjustment (P < 0.01)
| | | | | | Worse psychological adjustment (P < 0.01)
| | | | | | Disturbed menses (P < 0.01)
| | | | | | Bingeing (P = NS)
| | | | | | Vomiting (P = NS)
| | | | | | Sense of ineffectivenss (P = NS)
| | | | | | Dependency (P = NS)
| | | | | | Social and educational/vocational adjustment (P = NS)
| | | | | | Distribution among the categories of outcome by symptoms, N
| | | | | | Recovered: 18
| | | | | | Good: 20
| | | | | | Intermediate: 24
| | | | | | Poor: 9
| | | | | | Mean BMI:
| | | | | | Total: 18.5
| | | | | | Recovered: 20.2
| | | | | | Good: 20.3
| | | | | | Intermediate: 18.0
| | | | | | Poor: 13.7
| | | | | | Diff between groups (P = NR)
| | | | | | Educational/vocational:
| | | | | | Recovered: 0.11
| | | | | | Good: 0.60
| | | | | | Intermediate: 0.25
| | | | | | Poor: 1.0
| | | | | | Diff between groups (P < 0.001)
| | | | | | Pairwise group comparisons (P = NR)
| | | | | | Comorbid psychiatric dx:
| | | | | | Any Lifetime dx:
| | | | | | Diff between recovered vs 3 other groups (P = NS)
| | | | | | Current psychiatric dx:
| | | | | | Diff between recovered versus all other groups:
| | | | | | Major affective disorder (P < 0.01)
| | | | | | Anxiety disorders (P < 0.05)
| | | | | | Phobias (P < 0.05)
| | | | | | Recovered less comorbidity.
| | | | | | Diff between good and intermediate (P = NS)
| | | | | | ED dx and outcome category at 10 yr FU:
| | | | | | No dx:
| | | | | | Total: 18 (23.7%)
| | | | | | Recovered: 18
| | | | | | Good: 0
| | | | | | Intermediate: 0
| | | | | | Poor: 0
| | | | | | Diff between groups (P = NR)
| | | | | | EDNOS:
| | | | | | Total: 27 (35.5%)
| | | | | | Recovered: 0
| | | | | | Good: 10
| | | | | | Intermediate: 17
| | | | | | Poor: 0
| | | | | | Diff between groups (P = NR)
| | | | | | BN:
| | | | | | Total: 17 (22.4%)
| | | | | | Recovered: 0
| | | | | | Good: 10
| | | | | | Intermediate: 7
| | | | | | Poor: 0
| | | | | | Diff between groups (P = NR)
| | | | | | AN:
| | | | | | Total: 7 (9.2%)
| | | | | | Recovered: 0
| | | | | | Good: 0
| | | | | | Intermediate: 0
| | | | | | Poor: 7
| | | | | | Diff between groups (P = NR)
| | | | | | AN/BN
| | | | | | Total: 2 (2.6%)
| | | | | | Recovered: 0
| | | | | | Good: 0
| | | | | | Intermediate: 0
| | | | | | Poor: 2
| | | | | | Diff between groups (P = NR)
| | | | | | Treatment during FU:
| | | | | | Rehospitalized for tx of AN during FU: 23 (32%)
| | | | | | # hospitalization, mean (SD) (range): 2.7 (2.3) (1 – 8)
| | | | | | Rehospitalized for psychiatric problems other than AN: 11 (16%)
| | | | | | # hospitalizations, mean (SD) (range): 3.3 (3.1) (1 – 10)
| | | | | | Outpatient tx:
| | | | | | 54 (76%)
| | | | | | Mos of tx, mean (SD) (range):
| | | | | | 23.5 (26.4) (1 – 111)
Authors, year: | To compare patients with restricting AN and binge/purge AN on measures of impulsivity, course and long-term (8–12 yrs) outcome | Inclusion: | Mean Age at Intake, yrs: | Score: | Study Methods | Descriptive Findings
Eddy, Keel, Dorer et al., 2002 | | DSM III-R criteria for AN and/or BN. Reclassified to DSM IV criteria for subtype. Female, age 12 or older, residence within 200 miles of study site | ANR Pure: 20.8 | Fair | Schedule for Affective Disorders and Schizophrenia - Lifetime Version to diagnose Axis I disorders, Structured Interview for DSM III Personality Disorders to diagnose Axis II disorders. FU interviews were conducted using the Eating Disorders Longitudinal Interview FU Evaluation modified to include a section on eating disorders derived from the Diagnostic Interview Schedule. 6 point Psychiatric Status Rating scale was used to determine ED outcome. | At intake:
Design: | | Exclusion: | ANR Not Pure: 23.8 | Method of diagnosis: | Outcome Categories: | Duration of illness, years:
Case series | | Evidence of organic brain syndrome or terminal illness and lack of fluency in English | ANBP: 22.7 | Independent Clinician Diagnosis | ANR Pure: No lifetime history of binging or purging at intake or during first 3 mos. of study | ANR Pure: 3.4
Comparison Group: | | Recruitment: | Sex: | Funding | ANR Not Pure: History of binging and purging behavior at intake, infrequent binge/purge behavior at intake (i.e. at least once weekly), or binge/purge behavior during first 3 mos. of study | ANR Not Pure: 3.4
No | | Patients who sought tx at one of participating facilities and met DSM III-R criteria for AN, restricting type, AN, binge/purge type, or BN recruited | Female: 100% | Not reported | ANBP: full criteria for AN and regularly (at least once weekly) engaged in binge/purge behaviors (defined as vomiting, diuretic use, laxative use) | ANBP: 6.5
Location: | | Sample size: | Race/ethnicity: | | Full recovery: absence of symptomatology or the presence of minimal symptomatology for at least 8 consecutive weeks. | Diff between groups (P = 0.002)
Boston, MA | | N = 246 subjects (136 AN) | Not reported | | Relapse: return of full criteria symptomatology for at least 1 week following a period of full recovery. | Percent IBW:
Years followed: | | N = 51 AN restricting type (ANR) | | | Overall functioning and symptomatology: based on monthly 100-point Global Assessment of Severity scale ratings. | ANR Pure: 75%
8–12 (minimum 7 yrs, median 8 yrs FU) | | - N = 24 ANR “pure”; - N = 27 ANR “not pure | | | Statistical Analyses | ANR Not Pure: 75%
| | N = 85 AN binge/purge (ANBP) | | | For ordered variables, two-way comparisons using Wicoxon rank sum test and three way comparisons using Kendall's tau. For dichotomous outcomes, two-way comparisons using chi-square or Fisher exact test and three way comparisons using exact logistic models containing linear and quadratic contrasts. | ANBP: 82%
| | N = 110 BN | | | Exact logistic regression and ordinary regression models used to control for duration of illness. | Diff between groups (P <0.001)
| | Loss to FU Reasons: | | | | History of MDD, %:
| | 9 (3.7%) died (all AN: N = 2; AN Pure: N = 2; AN Not Pure: N = 5 ANBP). | | | | ANR Pure: 71%
| | Cause of death NR | | | | ANR Not Pure: 59%
| | Attrition rate: 7%. | | | | ANBP: 71%
| | | | | | Diff between groups (P = NS)
| | | | | | History of Hospitalization:
| | | | | | ANR Pure: 54%
| | | | | | ANR Not Pure: 70%
| | | | | | ANBP: 40%
| | | | | | Diff between groups (P = NS)
| | | | | | Personality Disorder, %:
| | | | | | ANR Pure: 22%
| | | | | | ANR Not Pure: 55%
| | | | | | ANBP: 38%
| | | | | | Diff between groups (P = NS)
| | | | | | Global Assessment of Severity Scale:
| | | | | | ANR Pure: 53.5
| | | | | | ANR Not Pure: 42.5
| | | | | | ANBP: 50.0
| | | | | | Diff between groups (P = NS)
| | | | | | History of Alcohol Abuse:
| | | | | | ANR Pure: 4%
| | | | | | ANR Not Pure: 11%
| | | | | | ANBP: 19%
| | | | | | Diff between groups (P =NS)
| | | | | | History of Drug Abuse:
| | | | | | ANR Pure: 0%
| | | | | | ANR Not Pure: 13%
| | | | | | ANBP: 16%
| | | | | | Diff between groups (P = 0.04)
| | | | | | History of Kleptomania:
| | | | | | ANR Pure: 0%
| | | | | | ANR Not Pure: 7%
| | | | | | ANBP: 13%
| | | | | | Diff between groups (P = NS)
| | | | | | History of Suicidality:
| | | | | | ANR Pure: 4%
| | | | | | ANR Not Pure: 29%
| | | | | | ANBP: 27%
| | | | | | Diff between groups (P = .04)
| | | | | Cox models used to compare survival across diagnostic groups and control for duration of illness. | Borderline Personality Disorder:
| | | | | | ANR Pure: 0%
| | | | | | ANR Not Pure: 10%
| | | | | | ANBP: 9%
| | | | | | Diff between groups (P = NS)
| | | | | | Association between binge-purge behaviors in AN and course and outcome variables:
| | | | | | Full recovery:
| | | | | | ANR Pure: 45.6%
| | | | | | ANR Not Pure: 21.5%
| | | | | | ANBP: 38.6%
| | | | | | Diff between groups (P = NS)
| | | | | | Partial Recovery:
| | | | | | ANR Pure: 87.5%
| | | | | | ANR Not Pure: 85.9%
| | | | | | ANBP: 87.1%
| | | | | | Diff between groups (P = NS)
| | | | | | Relapse:
| | | | | | ANR Pure: 31.4%
| | | | | | ANR Not Pure: 46.7%
| | | | | | ANBP: 67.8%
| | | | | | Diff between groups (P = NS)
| | | | | | Deaths:
| | | | | | ANR Pure: 8.3%
| | | | | | ANR Not Pure: 7.4%
| | | | | | ANBP: 5.9%
| | | | | | Diff between groups (P = NS)
| | | | | | Global Assessment of Severity Scale:
| | | | | | ANR Pure: 59
| | | | | | ANR Not Pure: 52
| | | | | | ANBP: 55
| | | | | | Diff between groups (P = NS)
| | | | | | Category Crossovers by 8 yrs FU (median):
| | | | | | ANRs:
| | | | | | N = 28 of the ANR's became ANBP
| | | | | | N = 10 of ANR Pure became ANBP
| | | | | | N = 18 of ANR Not Pure became ANBP
| | | | | | N = 4 of ANR Pures who became ANBP had onset of binging and purging
| | | | | | N = 3 of ANR Pures who became ANBP had onset binging only
| | | | | | N = 3 of ANR Pures who became ANBP had onset purging only
| | | | | | N = 14 of ANR group did not develop ANBP
| | | | | | N = 4 of those who remained ANR were fully recovered
| | | | | | N = 4 of those who remained ANR were partially recovered
| | | | | | N = 6 of those who remained ANR continued to meet full criteria for ANR
| | | | | | For those who crossed over from ANR to ANBP, the majority (ANR, 51.5%; ANR Pure, 37.8%; ANR Not Pure, 65%) occurred during the first five years of FU or by a median of 8.4 yrs of illness
Authors, yr: | To examine issues regarding course and long-term outcome of AN. | Inclusion: | Mean Age at tx start (SD) | Score: | Study Methods: | Results:
Fichter and Quadflieg, 1999 | | Females | 24.9 (6.7) yrs | Good | Patients assessed at admission to inpatient, discharge from inpatient, 2 yrs, 6 yrs FU. | Descriptives
Design: | | DSM IV for AN | Sex: | Method of dx: | For FU, patients sent questionnaire packet to complete. After packet returned, interview conducted by specially trained psychologists and physicians. Those not able to do long interview were given shorter version. Long interview were face to face or by phone, short by phone only. | Mean BMI (kg/cm ^ 2 ^ ) (SD)
Case Series | | Admitted to inpatient ED tx | Female 100% | Specially trained psychologists or physician using | | Tx start - 14.3 (1.7)
Comparison Group: | | Exclusion: | Race/ethnicity: | DSM IV criteria for AN based on interview and/or questionnaire data. | | Discharge from tx - 15.5 (1.7)
No | | None stated | NR | Funding | | 2 yr FU - 17.1 (3.4)
Location: | | Recruitment: | Mean BMI (kg/cm ^ 2 ^ ) at tx start (SD) | Wilhelm-Sander-Stiftung, Munich Germany; Bundesministerium fur Bildung, Forschung und Technologie in Germany | | 6 yr FU - 17.9 (2.8)
Germany | | Females who where dx'ed with AN and admitted to ED inpatient program (Klinik Roseneck) in Upper Bavaria Germany from 1985-1988. | 14.3 (1.7) | | Statistical Method: | ED diagnostic outcome (DSM IV):
Yrs followed: | | Sample size: | Duration of AN symptoms before tx start (SD) | | Repeated measures MANOVAs | 2 yr FU:
2 yr FU: 2.5 (0.9) | | Initial sample: | 6.3 (4.8) yrs | | Pairwise t tests | AN: 36.6%
6 yr FU: 6.2 (.9) | | (N = 103) | Age onset (SD) | | Longitudinal comparisons used sets complete for all time points. | BN: 9.9%
| | Loss to FU: | 18.5 (6.4) yrs | | | BED: 0
| | Death (N = 6) | Discharge status | | | EDNOS: 3.0%
| | Traffic accident during exercise = 1 | Normal: 85 | | | None: 45.5%
| | Cardiac and renal failure = 2 | Premature: 1 | | | 6 yr FU:
| | Hypocalcemia = 2 | By team: 3 | | | AN: 26.8%
| | Cardiac failure and cachexia = 1 | By mutual agreement: 13 | | | BN: 9.9% (16.8% cumulative)
| | Not reached (N = 1) | Improvement at discharge: | | | BED: 0
| | Refused to participate (N = 1) | Sig: 16 (15.8%) | | | EDNOS: 2.0%
| | Analysis Sample: | Marked: 44 (43.6%) | | | None: 55.4%
| | 2 yr FU (N = 98) | Slight: 30 (29.7%) | | Outcomes | PSR ED Symptoms Ratings:
| | 6 yr FU (N = 95) | Unchanged: 9 (8.9%) | | SIAB-P, supplemented by PSR | 2 yr FU:
| | | Slightly worse: 1 | | Global outcomes: aggregate of 10 outcome categories | Marked: 30.4%
| | | Marked worse: 1 | | - Good - outcome of 1 or 0; - Intermediate - outcome of 2; - Poor - outcome of 3–4 | Partial Remission: 30.4%
| | | Duration of tx (days) (SD): | | M-R general outcome | Residual: 23.9%
| | | 118.6 (49) | | - Good - within normal range and normal menstruation; - Intermediate - wt not consistently in normal range or menstrual irreg.; - Poor - wt below normal, menstruation absent or nearly absent | Usual self: 15.3%
| | | Education: | | | 6 yr FU:
| | | < 9 yrs: 1.9% | | | Marked: 30.4%
| | | > 9 yrs: 68.9% | | | Partial Remission: 25.0%
| | | 13+ yrs: 26.2% | | | Residual: 21.4%
| | | University degree: 2.9% | | | Usual self: 23.2%
| | | | | | Global outcomes
| | | | | | Good: 34.7%
| | | | | | Intermediate: 38.6%
| | | | | | Poor: 20.8%
| | | | | | Dead: 5.9%
| | | | | | Menstruation:
| | | | | | 2 yr FU:
| | | | | | Normal Menses: 21 (22.8%)
| | | | | | Irreg menses: 9 (9.8%)
| | | | | | Amenorrhea: 48 (52.2%)
| | | | | | No period other reasons: 2 (2.2%)
| | | | | | OCP or hormones: 12 (13.0%)
| | | | | | 6 yr FU:
| | | | | | Normal Menses: 34 (37%)
| | | | | | Irreg menses: 12 (13.0%)
| | | | | | Amenorrhea: 22 (23.9%)
| | | | | | No period other reasons: 7 (7.6%)
| | | | | | OCP or hormones: 17 (18.5)
| | | | | | M-R outcomes:
| | | | | | 2 yr
| | | | | | Good: 13 (12.9%)
| | | | | | Intermediate: 20 (19.8%)
| | | | | | Poor: 63 (62.3%)
| | | | | | 6 yr
| | | | | | Good: 25 (26.9%)
| | | | | | Intermediate: 23 (24.7%)
| | | | | | Poor: 39 (41.9%)
| | | | | | Diff in course of disease AN-R and AN-BP (P = NS)
| | | | | | Comorbidity rates ar 6 yr FU (N = 75):
| | | | | | Borderline Personality Disorder: 12%
| | | | | | Substance abuse (excl. lax): 20%
| | | | | | Mood disorders: 53%
| | | | | | Anxiety disorders: 32%
| | | | | | Change over time in EDI (N = 59)
| | | | | | Total
| | | | | | Beginning of therapy vs 2 yr FU (P < 0.05) Improved
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.01) Improved
| | | | | | End of therapy vs 2 yr FU (P < 0.001) Worsened
| | | | | | End of therapy vs 6 yr FU (P < 0.05) Worsened
| | | | | | Drive for Thinness
| | | | | | Beginning of therapy vs 2 yr FU (P < 0.01) Improved
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.01) Improved
| | | | | | End of therapy vs 2 yr FU (P < 0.001) Worsened
| | | | | | End of therapy vs 6 yr FU (P < 0.01) Worsened
| | | | | | Bulimia
| | | | | | Beginning of therapy vs 2 yr FU (P = NS)
| | | | | | Beginning of therapy vs 6 yr FU (P = NS)
| | | | | | End of therapy vs 2 yr FU (P < 0.001) Worsened
| | | | | | End of therapy vs 6 yr FU (P < 0.001) Worsened
| | | | | | Body dissatisfaction
| | | | | | Beginning of therapy vs 2 yr FU (P = NS)
| | | | | | Beginning of therapy vs 6 yr FU (P = NS)
| | | | | | End of therapy vs 2 yr FU (P = NS)
| | | | | | End of therapy vs 6 yr FU (P = NS)
| | | | | | Ineffectiveness
| | | | | | Beginning of therapy vs 2 yr FU (P < 0.05) Improved
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.01) Improved
| | | | | | End of therapy vs 2 yr FU (P < 0.001) Worsened
| | | | | | End of therapy vs 6 yr FU (P < 0.05) Worsened
| | | | | | Perfectionism
| | | | | | Beginning of therapy vs 2 yr FU (P = NS)
| | | | | | Beginning of therapy vs 6 yr FU (P = NS)
| | | | | | End of therapy vs 2 yr FU (P = NS)
| | | | | | End of therapy vs 6 yr FU (P = NS)
| | | | | | Change over time in SIAB (N = 52)
| | | | | | Total scale
| | | | | | Beginning of therapy vs 2 yr FU (P < 0.001) Improved
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.001) Improved
| | | | | | End of therapy vs 2 yr FU (P < 0.01) Worsened
| | | | | | End of therapy vs 6 yr FU (P = NS)
| | | | | | 2 yr FU vs 6 yr FU (P < 0.001) Improved
| | | | | | Body image and ideal of thinness
| | | | | | Beginning of therapy vs 2 yr FU (P < 0.001) Improved
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.001) Improved
| | | | | | End of therapy vs 2 yr FU (P = NS)
| | | | | | End of therapy vs 6 yr FU (P = NS)
| | | | | | 2 yr FU vs 6 yr FU (P = NS)
| | | | | | Depression
| | | | | | Beginning of therapy vs 2 yr FU (P = NS)
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.001) Improved
| | | | | | End of therapy vs 2 yr FU (P < 0.01) Worsened
| | | | | | End of therapy vs 6 yr FU (P < 0.01) Improved
| | | | | | 2 yr FU vs 6 yr FU (P < 0.001) Improved
| | | | | | Anxieties and obsessions
| | | | | | Beginning of therapy vs 2 yr FU (P = NS)
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.001) Improved
| | | | | | End of therapy vs 2 yr FU (P < 0.01) Worsened
| | | | | | End of therapy vs 6 yr FU (P < 0.05) Improved
| | | | | | 2 yr FU vs 6 yr FU (P < 0.001) Improved
| | | | | | Change over time SCL-90 (N = 53)
| | | | | | Global Severity Index
| | | | | | Beginning of therapy vs 2 yr FU (P < 0.01) Improved
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.01) Improved
| | | | | | End of therapy vs 2 yr FU (P < 0.01) Worsened
| | | | | | End of therapy vs 6 yr FU (P = NS)
| | | | | | Positive Symptom Total
| | | | | | Beginning of therapy vs 2 yr FU (P < 0.01) Improved
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.001) Improved
| | | | | | End of therapy vs 2 yr FU (P < 0.05) Worsened
| | | | | | End of therapy vs 6 yr FU (P = NS)
| | | | | | Positive Symptom Distress Index
| | | | | | Beginning of therapy vs 2 yr FU (P < 0.01) Improved
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.01) Improved
| | | | | | End of therapy vs 2 yr FU (P < 0.001) Worsened
| | | | | | End of therapy vs 6 yr FU (P < 0.05) Worsened
| | | | | | Somatization
| | | | | | Beginning of therapy vs 2 yr FU (P < 0.05) Improved
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.05) Improved
| | | | | | End of therapy vs 2 yr FU (P = NS)
| | | | | | End of therapy vs 6 yr FU (P = NS)
| | | | | | Obsessive-compulsive disorder
| | | | | | Beginning of therapy vs 2 yr FU (P = NS)
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.01) Improved
| | | | | | End of therapy vs 2 yr FU (P < 0.01) Worsened
| | | | | | End of therapy vs 6 yr FU (P = NS)
| | | | | | Interpersonal Sensitivity
| | | | | | Beginning of therapy vs 2 yr FU (P < 0.05) Improved
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.01) Improved
| | | | | | End of therapy vs 2 yr FU (P < 0.001) Worsened
| | | | | | End of therapy vs 6 yr FU (P < 0.05) Worsened
| | | | | | Depression
| | | | | | Beginning of therapy vs 2 yr FU (P < 0.01) Improved
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.001) Improved
| | | | | | End of therapy vs 2 yr FU (P < 0.01) Worsened
| | | | | | End of therapy vs 6 yr FU (P < 0.05) Worsened
| | | | | | Anxiety
| | | | | | Beginning of therapy vs 2 yr FU (P = NS)
| | | | | | Beginning of therapy vs 6 yr FU (P = NS)
| | | | | | End of therapy vs 2 yr FU (P = NS)
| | | | | | End of therapy vs 6 yr FU (P = NS)
| | | | | | Anger-hostility
| | | | | | Beginning of therapy vs 2 yr FU (P = NS)
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.01) Improved
| | | | | | End of therapy vs 2 yr FU (P < 0.05) Worsened
| | | | | | End of therapy vs 6 yr FU (P = NS)
| | | | | | BDI (N = 62)
| | | | | | Beginning of therapy vs 6 yr FU (P < 0.001) Improved
| | | | | | End of therapy vs 6 yr FU (P < 0.05) Worsened
| | | | | | Prognostic factors based on PSR
| | | | | | 2 yr FU
| | | | | | Early onset AN (P < 0.05) Worse
| | | | | | Low BMI at end of tx (P < 0.01) Worse
| | | | | | 6 yr FU
| | | | | | Binge in mo before tx (P < 0.05) Worse
| | | | | | Other mental dx prior to tx (P < 0.05) Worse
| | | | | | Low body wt at end of tx (P < 0.05) Worse
Authors, yr: | To determine predictors of serious suicide attempts in women with AN and BN. | Inclusion: | Mean Age: | Score: | Study Methods | Descriptive Results
Franko et al., 2004 | | Female, English speaking, meet full criteria for AN and/or BN, at least 12 yrs of age, reside within 200 miles of the study site. | 24.8 (range: 13 – 45) at entry to the study. | Good | FU interviews conducted every 6 – 12 mos in person when possible. | Baseline, Reported hx of suicide attempts prior to study entry:
Design: | | Exclusion: | Sex: | Method of dx: | Statistical Methods | AN: 30.1%
Case series | | Organic brain syndrome or terminal illness. | Female:100% | LIFE-EAT-II and the PSR scale | Non-parametric tests to examine diff on self-report measures administered at intake between subjects who made suicide attempts and those who did not. | BN: 22.7%
Comparison Group: | | Recruitment: | Race/ethnicity: | Funding | Kaplan-Meier survival analyses to determine time to first suicide attempt, and time-varying proportional hazards (Cox) regression models used to determine influence of baseline and course variables on time to first suicide attempt. | Rates of suicide attempts:
No | | 554 consecutive women who sought tx for eating disorder at Massachusetts General Hospital or other Boston area clinics between October 1987 and June 1990. | Non-Caucasian: 4% | NIMH, Rubenstein Foundation, and Harvard Eating Disorders Care | Multiple regression to predict time to first suicide attempt. | AN: 30 (22.1%)
Location: | | Sample Size | Mean duration of illness: | | | BN: 12 (10.9%)
Massachusetts, USA | | Initial sample: | 6.7 yrs | | | Death from suicide: N = 4 (none had a previous suicide attempt).
Yrs followed: | | Met dx criteria: N = 268 | (range: 3 mos – 21 yrs) | | | Diff between baseline self report measures for suicide attempters and non-attempters, mean (SD):
MeAN: 8.6 | | Agreed to participate: N = 229 | | | | AN
| | Additional participants identified: N = 21 | | | | EDI, drive for thinness (P = NS)
| | Reasons for loss to FU: | | | | EDI, Bulimia (P = NS)
| | Drop out prior to first FU: N = 4 | | | | EDI, body dissatisfaction (P = NS)
| | Analysis Sample | | | | EDI, ineffectiveness:
| | N = 246 | | | | - attempters: 15.2 (8.6); - non-attempters: 11.4 (7.8); - (P = 0.04); Attempters did worse
| | AN-Restricting: 51 | | | | EDI, perfectionism (P = NS)
| | AN-Binge Purge: 85 | | | | EDI, interpersonal distrust (P = NS)
| | BN: 110 | | | | EDI, interoceptive awareness (P = NS)
| | | | | | EDI, maturity fears (P = NS)
| | | | | | BDI:
| | | | | | attempters: 27.6 (12.1)
| | | | | | non-attempters: 22.7 (11.3)
| | | | | | (P = 0.05). Attempters had greater depression.
| | | | | | Symptom distress (P = NS)
| | | | | | Global severity index (P = NS)
| | | | | | Positive symptom total (P = NS)
| | | | | | BN
| | | | | | EDI, drive for thinness (P = NS)
| | | | | | EDI, Bulimia (P = NS)
| | | | | | EDI, body dissatisfaction (P = NS)
| | | | | | EDI, ineffectiveness:
| | | | | | - attempters: 14.6 (7.1); - non-attempters: 8.4 (6.1); - (P = 0.007); Attempters did worse
| | | | | | EDI, perfectionism (P = NS)
| | | | | | EDI, interpersonal distrust:
| | | | | | - attempters: 7.1 (4.0); - non-attempters: 4.5 (3.4); - (P = 0.04). Attempters did worse.
| | | | | | EDI, interoceptive awareness
| | | | | | - attempters: 17.7 (7.6); - non-attempters: 10.9 (5.9); - (P = 0.003). Attempters did worse
| | | | | | EDI, maturity fears:
| | | | | | - attempters: 7.6 (7.3); - non-attempters: 3.7 (4.3); - (P = 0.03). Attempters did worse.
| | | | | | BDI:
| | | | | | attempters: 27.0 (11.7)
| | | | | | non-attempters: 19.6 (9.5)
| | | | | | (P = 0.03). Attempters had greater depression.
| | | | | | Symptom distress:
| | | | | | - attempters: 2.2 (0.46); - non-attempters: 1.9 (1.4); - (P = 0.006). Attempters did worse
| | | | | | Global severity index:
| | | | | | - attempters: 1.6 (0.49); - non-attempters: 1.0 (0.54); - (P = 0.002). Attempters did worse.
| | | | | | Positive symptom total:
| | | | | | - attempters: 64.0 (11.7); - non-attempters: 47.7 (18.0); - (P = 0.003). Attempters did worse.
| | | | | | Multivariate Results
| | | | | | Predictors of time to first suicide attempt during course of study-hypothesis testing results:
| | | | | | AN
| | | | | | Hx of suicide attempt at intake (P < 0.009)
| | | | | | Eating disorder symptomatology (P = NS)
| | | | | | Severity of drug use (P < 0.01)
| | | | | | Alcohol use (P = NS)
| | | | | | BN
| | | | | | Laxative use (P < 0.05)
| | | | | | Hx of drug use disorder prior to start of the study (P < 0.01)
| | | | | | AN
| | | | | | Hx of suicide attempt at intake: HM = 1.09, 95% CI (1.31 – 6.71) (P = 0.009); Shorter time to first attempt
| | | | | | Drug use: HM = 0.92, 95% CI (1.40 – 4.52) (P = 0.01); Greater use shorter time
| | | | | | Individual therapy: HM = 3.54, 95% CI (1.20 – 10.42) (P = 0.013); Yes, shorter time
| | | | | | Neuroleptic meds: HM = 5.03, 95% CI (1.50 – 16.86) (P = 0.02); Yes, shorter time
| | | | | | Age of onset: HM = 1.06, 95% CI (1.00 – 1.12) (P = 0.05); Older age, shorter time
| | | | | | Group therapy: HM = 2.35, 95% CI (1.00 – 5.53) (P = 0.06)
| | | | | | Severity of depression: HM = 1.21, 95% CI (0.99 – 1.50) (P = NS)
| | | | | | Alcohol use: HM = 1.54, 95% CI (0.99 – 1.04) (P = NS)
| | | | | | BN
| | | | | | Group therapy: HM = 11.32, 95% CI (2.33 – 55.02) (P = 0.002)
| | | | | | Yes, shorter time
| | | | | | Age of onset: HM = 0.82, 95% CI (0.70 – 0.97) (P = 0.008)
| | | | | | Younger age, shorter time
| | | | | | Hx of drug use disorder: HM = 8.94, 95% CI (1.87 – 42.77) (P = 0.009)
| | | | | | Greater hx, shorter time
| | | | | | Individual therapy: HM = 10.39, 95% CI (1.03– 105.12) (P = 0.020)
| | | | | | Yes, shorter time
| | | | | | Paranoid personality disorder at intake: HM = 66.5, 95% CI (3.60 – 129.84) (P = 0.020)
| | | | | | Yes, shorter time
| | | | | | Severity of laxative use: HM = 1.21, 95% CI (1.50 – 46.30) (P = 0.022)
| | | | | | More, shorter time
| | | | | | Psychiatric hospitalization: HM = 10.75, 95% CI (1.16 – 99.86) (P = NS)
Authors, yr: | To analyze stability of personality disorders over a 6-yr period after reported AN onset | Inclusion: | Age, mean (95% CI): | Score: | Study Methods: | Descriptive Results
Gillberg, Råstam, and Gillberg, 1995 | | Cases: | Cases: 21.0 (20.5–21.4) | Good | Psychiatric interview, blinded to original disease status. Performed the SCID-II, Dewey Social Awareness Test, examined individual neurodevelpmentally/ neuro-logically, and administered the Wechsler Adult Intelligence Sale-Revised. | AN Recovery (self report): 47%
Companion article: | | DSM III-R for AN | Comparisons: 20.8 (20.3–21.3) | Method of dx: | Statistical Methods: | Comparison of Personality Disorders between AN and control group at age 21 (mean of 6 yrs after onset)
Gillberg, Råstam, Gillberg, 1994 | | Born 1970 | Sex: | Structured interview using the SCID-I | Chi-square comparisons | Cluster A
Design: | | AN onset < 18 yrs old | Women in AN sample: N = 48 | Funding | | All categories (P = NS)
Prospective cohort | | Comparison: | Race/ethnicity: | Swedish Medical Research Council, Swedish Social Research Council, Swen Jerring Foundation, Fulbright Commission, Wilhelm and Martina Lundgren Foundation, Sennerdahl Foundation | | Cluster B
Comparison Group: | | Matched to cases on age, sex, school | NR | | | All categories (P = NS)
Yes | | Exclusion: | Age of AN onset, mean (range): | | | Cluster C
Location: | | Cases: None | 14.3 (13.9–14.7) | | | Avoidant: Cases (14%) Comparison (2%) (P < 0.07)
Göteburg, Sweden | | Comparisons: None | | | | Dependent (P = NS)
Yrs followed: | | Recruitment: | | | | Obsessive-compulsive: Cases (29.5%) Comparison (6%) (P < 0.001)
6.7 from onset of AN (6.3–7.0) | | Cases: From total population of Göteburg, Sweden, born in 1970 and developing AN before age 18; pooled with second population screening sample reported by school and hospital health care workers during FU. Some clinically referred and some screened through school nurses and doctors, pediatricians, and child psychiatrists | | | | Passive-aggressive (P = NS)
Cases: 4.9 from first exam | | Comparisons: Same schools as AN group | | | | Any cluster C: Cases (37%) Comparison (10%) (P < 0.001)
Comparisons: | | Sample size: | | | | Other
4.6 from first exam | | Cases: 51 | | | | Self-defeating (P = NS)
| | Comparisons: 51 | | | | Any SCID personality disorder: Cases (41%) Comparison (18%) (P < 0.02)
| | | | | | 2 or more SCID personality disorders: Cases (23.5%) Comparison (2%) (P < 0.01)
| | | | | | Comparison of Autism Spectrum Disorders and Empathy Disorders
| | | | | | Asperger's syndrome: Cases (12%) Comparison (0%) (P < 0.05)
| | | | | | Any autistic like condition: Cases (20%) Comparison (0%) (P < 0.001)
| | | | | | Empathy disorder: Cases (29.5%) Comparison (4%) (P < 0.002)
| | | | | | OCD/OCPD/Asperger syndrome/autistic-like condition at both 16 and 21:
| | | | | | Cases (N = 23) Comparison (N = 2) (P < 0.01)
| | | | | | Concurrence of Axis II and Axis I Disorders
| | | | | | No axis II/ASD-no axis I: Cases (25.5%) Comparison (70%) (P < 0.0001)
| | | | | | No axis II/ASD-at least 1 axis I (P = NS)
| | | | | | At least 1 axis II/ASD-at least 1 axis I: Cases (31%) Comparison (12%) (P < 0.01)
| | | | | | At least 1 axis II/ASD-no axis I (P = NS)
Authors, yr: | To analyze whether in the intermediate-term, outcome is worse in AN than comparisons; to evaluate the contribution of empathy deficit associated with AN to outcomes; to compare AN outcome in this sample to those of previous studies using the M-R scales | Inclusion: | Age of AN onset: | Score: | Study Methods: | Descriptive Results
Gillberg, Råstam, Gillberg 1994 | | Cases: | 14.3 yrs | Good | At time of dx, all participants, then children and adolescents, and their mothers were interviewed by a psychiatrist. At FU, both groups were screened by another psychiatrist/psychologist blind to the original group status, via SCID-II for personality disorder dx, clinician-based capacity for empathy, Dewey social awareness test, neurological testing, WAIS-R, wt, and ht (self-report). All individuals also examined by psychiatrist to administered the first interview, using SCID-I for Axis I disorders, the M-R AN outcome scales and a rating of empathic skills. At end of interview, DSM III-R dx made independently by both clinicians; empathy dx was made conjointly by both. | Recovery status AN group, Morgan Russell self-progress rating:
Design: | | DSM III-R for AN | Range: 13.9–14.7 | Method of dx: | Outcome measures | Recovered: 47%
Prospective cohort | | Born 1970 | Mean Age at First Exam: | Structured interview using the SCID-I | Recovered/not-recovered for individuals dx in teenage yrs (interview data from M-R scale), | Not-recovered: 53%
Comparison Group: | | AN onset < 18 yrs old | Cases: 16.1 (95% CI: 15.7–16.5) | Funding | Avgd scale scores according to Morgan-Russell interview | Not recovered but improved: 39%
Yes | | Comparison: | Comparisons: 16.0 (95% CI: 15.5–16.5) | NR | Good, intermediate and poor outcome: good = nrml body wt (100 +- 15%avg body wt.), | Not recovered but static: 12%
Location: | | Matched to cases on age, sex, school | Mean Age at FU: | | Intermediate = normal or near normal wt and/or menstrual abnormalities, poor = low wt and absent or scanty menstruation. (BMI or % wt details regarding these definitions were NR). | Not recovered and worse: 2%
Göteburg, Sweden | | Exclusion: | Cases: 21 (95% CI: 20.5–21.4) | | Statistical Methods: | Some type of ED in AN group: 44%
Yrs followed: | | Cases: None | Comparisons: 20.8 (95% CI: 20.3–21.3) | | Chi square tests for matched pairs were used. | Avg total M-R Scores:
6.7 from onset of AN (6.3–7.0) | | Comparisons: None | Sex (both groups), N: | | | Cases: very poor: 39% (avg score of 8.5 or less)
Cases: 4.9 from first exam | | Recruitment: | Females: 96 | | | Good-Intermediate and Poor Outcome for AN group:
Comparisons: 4.6 from first exam | | Cases: From total pop of Göteburg, Sweden, born in 1970 and developing AN before age 18; pooled with second population screening sample reported by school and hospital health care workers during FU. Some clinically referred and some screened through school nurses and doctors, pediatricians, and child psychiatrists | Males:6 | | | Good: 41%
| | Comparisons: Same schools as AN group | Race/ethnicity: | | | Intermediate: 35%
| | Sample size: | NR | | | Poor: 24%
| | Cases: 51 | Min BMI kg/m^2^, mean: | | | Dietary Restriction and concern about body wt, M-R scale:
| | Comparisons: 51 | Cases: 14.9 (2.6) | | | Dietary Restriction
| | | Comparisons: NR | | | None: Cases: 47%, Comparisons: 88%
| | | BMI at first exam, kg/m^2^, mean: | | | Less than ½ timeCases: 18%, Comparisons: 12%
| | | Cases: 18.3 (2.9) | | | About ½ timeCases: 6%, Comparisons: 0
| | | Comparisons: NR | | | More than ½ timeCases: 4% Comparisons: 0
| | | BMI at FU, kg/m^2^, mean: | | | All the timeCases: 26% Comparisons: 0
| | | Cases: 21.2 (3.5) | | | Diff between groups (P < 0.001)
| | | Comparisons: NR | | | Worry about body wt or appearance
| | | | | | None: Cases:16% Comparisons: 57%
| | | | | | Less than ½ timeCases: 35% Comparisons: 31%
| | | | | | About ½ timeCases: 2% Comparisons: 8%
| | | | | | More than ½ timeCases: 10% Comparisons: 0
| | | | | | All the timeCases:37% Comparisons: 4%
| | | | | | Diff between groups (P < 0.001)
| | | | | | Body wt during last 6 mos:
| | | | | | Near avg all timeCases: 53% Comparisons:96%
| | | | | | Usually near avg, but occasionally deviant: Cases: 16% Comparisons: 4%
| | | | | | Always deviated: Cases: 18% Comparisons: 0
| | | | | | Always much deviated: Cases: 14% Comparisons: 0
| | | | | | Diff between groups (P < 0.001)
| | | | | | Menstruation:
| | | | | | Cases: halted menstruation never returned: 8%, Regular or cyclical menarche: 50%
| | | | | | Comparisons: Regular or cyclical menarche: 90%
| | | | | | Diff between groups (P < 0.001)
| | | | | | AN group tx type (specifically for ED) and outcome status:
| | | | | | Poorest outcome: 5 had no tx, 10 had only psychiatric tx (2, outpatient only; 9, family therapy, 1, individual psychotherapy).
| | | | | | Best outcomes, 3 no tx, 3 pediatrician support and zinc supplements, 2 met with psychiatrist ( < 8 times), 7 received therapy (>8 times)
| | | | | | Diff between groups (P = NS)
Authors, yr: | To analyze the associated physical and neuro-developmental problems over 5 yrs in individuals with AN, and matched comparisons. | Inclusion: | Age of AN onset: | Score: | Study Methods: | Descriptive Results
Gillberg, Råstam, and Gillberg 1994 | | Cases: | 14.3 yrs | Good | At time of dx, all participants, then children and adolescents, and their mothers were interviewed by a psychiatrist. At FU, another psychiatrist/psychologist blind to the original group status, screened both groups: via SCID-II for personality disorder dx, clinician-based capacity for empathy, Dewey social awareness test, neurological testing, WAIS-R, wt, and ht (self-report). All individuals also examined by psychiatrist who administered first interview, using SCID-I for Axis I disorders, M-R AN outcome scales, and a rating of empathic skills. At end of interview, DSM III-R dx made independently by both clinicians; empathy dx was made conjointly by both. | Wt at first screen, kg (SD):
Companion article: | | DSM III-R for AN | Range: 13.9–14.7 | Method of dx: | Neurodevelopmental exam included growth charts of wt and ht development from age 7 through time of 1^st^ exam; wt and ht immediately before onset of AN were compared to FU data | Cases: 49.4 (8.8), 95% CI (47.0–51.8)
Gillberg, Råstam, and Gillberg 1995 | | Born 1970 | Mean Age at First Exam: | Structured interview using the SCID-I | Outcome measures | Comparisons: 56.2 (6.6), 95% CI (54.4–58.0)
Design: | | AN onset < 18 yrs old | Cases: 16.1 95% CI (15.7–16.5) | Funding | At 16 yrs: Extreme underwt = BMI≤17; Extreme overwt = BMI ≥25. | Diff between groups (P < 0.01)
Prospective cohort | | Comparison: | Comparisons: 16.0 | NR | At 21 yrs: Extreme underwt = lowest wt ≤45kg; Extreme overwt = heaviest ≥80kg. | Wt at FU, kg (SD):
Comparison Group: | | Matched to cases on age, sex, school | 95% CI (15.5–16.5) | | Extreme shortness was dx in individuals who were shorter than the shortest individual in the comparison group. | Cases: 58.9 (6.6), 95% CI (54.4–58.0)
Yes | | Exclusion: | Mean Age at FU: | | Statistical Methods: | Comparisons: 58.2 (7.9), 95% CI (58.2–62.6)
Location: | | Cases: None | Cases: 21 | | Wilcoxon test for matched pairs were used. | Diff between groups (P = NR)
Göteburg, Sweden | | Comparisons: None | 95% CI (20.5–21.4) | | | Ht at first screen, cm (SD):
Yrs followed: | | Recruitment: | Comparisons: 20.8 | | | Cases: 164.3 (5.8), 95% CI (162.7–165.9)
6.7 from onset of AN (6.3–7.0) | | Cases: From total pop of Göteburg, Sweden, born in 1970 and developing AN before age 18; pooled with second population screening sample reported by school and hospital health care workers during FU. Some clinically referred and some screened through school nurses and doctors, pediatricians, and child psychiatrists | 95% CI (20.3–21.3) | | | Comparisons: 166.7 (6.9), 95% CI (164.8–168.8)
Cases: 4.9 from first exam | | Comparisons: Same schools as AN group | Sex (both groups), N: | | | Diff between groups (P = NS)
Comparisons: 4.6 from first exam | | Sample size: | Females: 96 | | | Ht at FU, cm (SD):
| | Cases: 51 | Males:6 | | | Cases: 166.2 (6.4), 95% CI (164.4–168.8)
| | Comparisons: 51 | Race/ethnicity: | | | Comparisons: 169.1 (6.8), 95% CI (167.2–171.0)
| | | NR | | | Diff between groups (P < 0.05)
| | | | | | BMI at first screen, kg/m^2^ (SD):
| | | | | | Cases: 18.3 (2.9) 95% CI (17.5–19.1)
| | | | | | Comparisons: 20.2 (1.9) (95% CI (19.7–20.8)
| | | | | | Diff between groups (P = NS)
| | | | | | BMI at FU, kg/m^2^ (SD):
| | | | | | Cases: 21.2 (3.5) 95% CI (20.2–22.2)
| | | | | | Comparisons: 21.2 (2.3) 95% CI (20.5–21.8)
| | | | | | Diff between groups (P = NS)
| | | | | | Extremely Underwt at first screen:
| | | | | | G1: 15
| | | | | | G2: 1
| | | | | | Diff between groups (P < 0.001)
| | | | | | Extremely Underwt at FU:
| | | | | | G1: 4
| | | | | | G2: 0
| | | | | | Diff between groups (P < 0.05)
| | | | | | Extremely Overwt at first screen:
| | | | | | G1: 1
| | | | | | G2: 0
| | | | | | Diff between groups (P = NR)
| | | | | | Extremely Overwt at FU:
| | | | | | G1: 3
| | | | | | G2: 0
| | | | | | Diff between groups (P < 0.05)
| | | | | | Extremely Short at first screen:
| | | | | | G1: 0
| | | | | | G2: 0
| | | | | | Diff between groups (P = NS)
| | | | | Study Methods: | Extremely Short at FU:
| | | | | At time of dx, all participants, then children and adolescents, and their mothers were interviewed by a psychiatrist. At FU, another psychiatrist/psychologist blind to the original group status, screened both groups: via SCID-II for personality disorder dx, clinician-based capacity for empathy, Dewey social awareness test, neurological testing, WAIS-R, wt, and ht (self-report). All individuals also examined by psychiatrist who administered first interview, using SCID-I for Axis I disorders, M-R AN outcome scales, and a rating of empathic skills. At end of interview, DSM III-R dx made independently by both clinicians; empathy dx was made conjointly by both. | G1: 6
| | | | | Neurodevelopmental exam included growth charts of wt and ht development from age 7 through time of 1^st^ exam; wt and ht immediately before onset of AN were compared to FU data | G2: 0
| | | | | Outcome measures | Diff between groups (P < 0.05)
| | | | | At 16 yrs: Extreme underwt = BMI≤17; Extreme overwt = BMI ≥25. | Physical Disorders:
| | | | | At 21 yrs: Extreme underwt = lowest wt ≤45kg; Extreme overwt = heaviest ≥80kg. | Diff between groups at baseline or FU (P = NS)
| | | | | Extreme shortness was dx in individuals who were shorter than the shortest individual in the comparison group. | Neurodevelopmental:
| | | | | Statistical Methods: | Fine and gross motor skills, tremor, mirror movements, handedness (P = NS)
| | | | | Wilcoxon test for matched pairs were used. | Dysdiadochokinesis, at both time patients:
| | | | | | G1: 10
| | | | | | G2: 1
| | | | | | Diff between groups (P < 0.01)
| | | | | | In terms of outcome, 20 AN individuals had “poor outcome” based on the Morgan Russell scale. Of those, 8 were dysdiadochokinesis group (P = NS).
Authors, yr: | To clarify the relationship between a range of presenting features, tx received, and medium to long-term outcome in AN. | Inclusion: | Mean Age | Score: | Study Methods | Descriptive Outcomes
Gowers et al., 2000 | | DSM III-R criteria for AN | 15.2 | Poor | Interviews in-person or by telephone. Some interviews with relatives or physician informants. Calculation of M-R Global Assessment Score | M-R Global Assessment Score Outcomes:
Design: | | Exclusion: | G1: 14.10 | Method of dx: | Outcome categories | Good:45.3%
Case series | | NR | G2: 15.6 | G1: K-SADS diagnostic interview | Good: wt maintained > 85% expected body wt, menstruation resumed and social functioning satisfactory; M-R Global Assessment Score ≥ 9 | Intermediate:30.7%
Comparison Group: | | Recruitment: | Sex: | G2: clinical assessment | Intermediate: substantial improvement in ED obtained with wt maintained > 85% of expected wt, but either menstruation not resumed or sig concern about eating and wt or was another psychosocial difficulty; M-R Global Assessment Score 6 – 9 | Poor: 20.0%
No | | 75 consecutive cases of adolescent-onset AN were drawn from a series attending a regional adolescent service. Of these, G1: 35 had participated in a prospective study of family values in AN and G2: 40 were immediately preceding cases presenting to the department | Males: N = 4 (all from G1) | Funding NR | Poor: still suffering ED and wt maintained < 85%; M-R Global Assessment Score < 6: 15 (20.0%) | Inadequate Information: 4.0%
Location: Britian | | Sample size: | Females: N = 71 | Funding | Statistical Analyses | Descriptive variables by outcomes:
Yrs followed: | | Initial sample: | Race/ethnicity: | NR | Data were examined for diffs between the two series on key presentation variables using ANOVA and chi square. | Age at onset, mean, yrs, mos:
G1: 2 | | N = 75 | NR | | Stepwise multiple regression to determine the relationship between covarying predictor variables with M-R Global Assessment Score at FU. | Good: 14, 3
G2: 3 to 7 | | Reasons for loss to FU: | Length of Illness (mos): | | | Intermediate: 13, 10
| | Insufficient information: N = 1 | 13 | | | Poor: 13, 11
| | Deceased: N = 2 | G1: 14.1 | | | Diff between groups (P = NS)
| | Analysis sample: | G2: 12.0 | | | Length of illness, mean, mos:
| | N = 73 | Wt, as % of expected wt: | | | Good: 11.1
| | Full outcome (including ht and wt) available for 56 | 76.5 | | | Intermediate: 14.5
| | | G1: 78.2 | | | Poor: 15.3
| | | G2: 75.1 | | | Diff between groups (P = NS)
| | | M-R Global Assessment Score: | | | Wt as % of mean matched population wt:
| | | 4.61 | | | Good: 81.3
| | | G1: 5.05 | | | Intermediate: 73.3
| | | G2: 4.24 | | | Poor: 70.7
| | | Subtype, Restricting, N: 44 | | | Diff between groups (P = 0.001)
| | | G1: 21 | | | Higher wt associated with better outcome
| | | G2: 23 | | | Presenting M-R Global Assessment Scale:
| | | Purging: | | | Good: 5.3
| | | N: 31 | | | Intermediate: 4.15
| | | G1: 14 | | | Poor: 3.68
| | | G2: 17 | | | Diff between groups (P = 0.001)
| | | | | | Higher MRGAS associated with better outcome
| | | | | | Never an inpatient:
| | | | | | Good: 31
| | | | | | Intermediate: 13
| | | | | | Poor: 7
| | | | | | Diff between groups (P = 0.001)
| | | | | | Never inpatient associated with better outcome
| | | | | | Multivariate Results
| | | | | | Predictors of M-R Global Assessment Scale score in step-wise regression
| | | | | | Inpatient admission (P = 0.0006)
| | | | | | Presenting MRGAS (P = 0.001)
Authors, year: | To determine the prevalence of lifetime and current psychiatric diagnoses in AN patients compared to comparisons. | Inclusion: | Mean Age, yrs (SD): | Score: | For General Psychiatric diagnoses: | Descriptive Findings:
Halmi, Eckert et al., 1991 | | All patients met modified Feighner diagnostic criteria for AN. Other details in Halmi et al., 1979. Comparisons matched patients on age, sex, and socioeconomic class. | Pre-tx: 20 (5.2) | Fair | Diagnostic Interview Schedule (Version III) used to interview patients, comparisons, and parents of both patients groups. Results were computer-scored, yielding a positive or negative score on every diagnosis for each subject. Any dx within the past year was considered ‘current’. A positive dx of a drug or alcohol disorder was made for “abuse without dependence”, “dependence without abuse”, abuse, and dependence. Obsessive-compulsive behaviors concerning food, weight, or body image were excluded as positive evidence of criteria for obsessive-compulsive behaviors. The Research Diagnostic Criteria-Family History (RDC-FH) method was used to obtain psychiatric dx of first-degree relatives from mothers of patients and comparisons. | Eating Disorder Dx at 10-yr FU:
Companion article: | | Exclusion: | 10 yr FU: 29 (5.2) | Method of diagnosis: | For ED dx at FU: A structured ED history was created from detailed information about binge frequency, laxative and diuretic abuse, typical anorectic attitudes, menstrual function, and weight changes. | AN =2, BN = 2, normal weight bulimia (NWB) = 14, ED-NOS = 24, no ED = 17.
Schork et al., 1994 | | Hx of eating disorder or body weight above normal range for comparisons; See Halmi et al., 1979, for more details. | Sex: | Prospective assessment using Feighner criteria; retrospective DSM-III-R. | Pearson's Chi-square test was used to compare differences in the prevalence of psychiatric disorders between patients and comparisons. | Lifetime DSM-III-R Dx in Patients by Dx at 10 yr FU and in Matched Comparisons, N:
Design: | | Recruitment: | Female | Funding | | Any Affective Disorder:
Case series | | Cases had previously participated in a 35-day hospital tx study comparing behavior therapy vs.medication (cyproheptadine). | Race/ethnicity: | NR | | Patients: 52; Comparisons: 14
Comparison Group: | | Comparisons recruited via advertisements in local newspapers and on local college campuses. | NR | | | Diff between groups (P = NR)
Yes | | Sample Size (N): | | | | Major depression:
Location: | | Completed tx: 76 | | | | Patients: 42; Comparisons: 13
USA (Iowa City, IA; Minneapolis, MN; White Plains, NY | | Completed FU: | | | | Diff between groups (P < 0.01)
Years followed: | | Patients: 62 | | | | Mania:
10 | | Comparisons: 62 | | | | Patients: 2; Comparisons: 1
| | Patients' mothers: 57 | | | | Diff between groups (P = NS)
| | Patients' fathers: 49 | | | | Dysthymia:
| | Comparisons mothers: 57 | | | | Patients: 20; Comparisons: 2
| | Comparisons fathers: 49 | | | | Diff between groups (P < 0.01)
| | Reasons for loss to FU: | | | | Bipolar:
| | 9 refused to participate, 5 deceased (causes unknown). | | | | Patients: 2; Comparisons: 0
| | | | | | Diff between groups (P = NS)
| | | | | | Atypical Bipolar:
| | | | | | Patients: 6; Comparisons: 0
| | | | | | Diff between groups (P < 0.01)
| | | | | | Anxiety Disorders:
| | | | | | Patients: 40; Comparisons: 13
| | | | | | Diff between groups (P = NS)
| | | | | | Obsessive-compulsive:
| | | | | | Patients: 16; Comparisons: 4
| | | | | | Diff between groups (P < 0.01)
| | | | | | Agoraphobia:
| | | | | | Patients: 9; Comparisons: 2
| | | | | | Diff between groups (P < 0.05)
| | | | | | Simple phobia:
| | | | | | Patients: 8; Comparisons: 9
| | | | | | Diff between groups (P = NS)
| | | | | | Social phobia:
| | | | | | Patients: 21; Comparisons: 2
| | | | | | Diff between groups (P < 0.01)
| | | | | | Panic:
| | | | | | Patients: 5; Comparisons: 0
| | | | | | Diff between groups (P = NS)
| | | | | | Schizophrenia:
| | | | | | Patients: 4; Comparisons: 0
| | | | | | Diff between groups (P = NS)
| | | | | | Alcohol abuse:
| | | | | | Patients: 5; Comparisons: 9
| | | | | | Diff between groups (P = NS)
| | | | | | Cannabis abuse:
| | | | | | Patients: 8; Comparisons: 15
| | | | | | Diff between groups (P = NS)
| | | | | | Amphetamine abuse:
| | | | | | Patients: 1; Comparisons: 5
| | | | | | Diff between groups (P = NS)
| | | | | | Barbiturates:
| | | | | | Patients: 0; Comparisons: 2
| | | | | | Diff between groups (P = NS)
| | | | | | Opioids:
| | | | | | Patients: 0; Comparisons: 1
| | | | | | Diff between groups (P = NS)
| | | | | | Hallucinogens:
| | | | | | Patients: 0; Comparisons: 1
| | | | | | Diff between groups (P = NS)
| | | | | | Antisocial personality:
| | | | | | Patients: 0; Comparisons: 2
| | | | | | Diff between groups (P = NS)
| | | | | | Tobacco:
| | | | | | Patients: 9; Comparisons: 11
| | | | | | Diff between groups (P = NS)
| | | | | | Psychosexual dysfunction:
| | | | | | Patients: 28; Comparisons: 16
| | | | | | Diff between groups (P < 0.05)
| | | | | | Homosexual:
| | | | | | Patients: 0; Comparisons: 1
| | | | | | Diff between groups (P = NS)
| | | | | | Comorbid DSM-II Dx at 10 yr FU, N (%):
| | | | | | No Dx:
| | | | | | Patients: 29 (46.8); Comparisons: 40 (64.5)
| | | | | | Diff between groups (P < 0.05)
| | | | | | Major depression:
| | | | | | Patients: 18 (29.0); Comparisons: 4 (6.4)
| | | | | | Diff between groups (P < 0.01)
| | | | | | Obsessive-compulsive:
| | | | | | Patients: 7 (11.3); Comparisons: 1 (1.6)
| | | | | | Diff between groups (P < 0.05)
| | | | | | Phobia:
| | | | | | Patients: 15 (24.2); Comparisons: 8 (12.9)
| | | | | | Diff between groups (P = NS)
| | | | | | Mania:
| | | | | | Patients: 1 (1.6); Comparisons: 1 (1.6)
| | | | | | Diff between groups (P = NS)
| | | | | | Dysthymia:
| | | | | | Patients: 15 (24.2); Comparisons: NR
| | | | | | Bipolar:
| | | | | | Patients: 2 (3.2); Comparisons: 0 (0)
| | | | | | Diff between groups (P = NS)
| | | | | | Panic disorder:
| | | | | | Patients: 3 (4.8); Comparisons: 1 (1.6)
| | | | | | Diff between groups (P = NS)
| | | | | | Alcohol abuse:
| | | | | | Patients: 2 (3.2) Comparisons: 4 (6.4)
| | | | | | Diff between groups (P = NS)
| | | | | | Schizophrenia:
| | | | | | Patients: 2 (3.2); Comparisons: 0 (0)
| | | | | | Diff between groups (P = NS)
| | | | | | Tobacco:
| | | | | | Patients: 9 (14.5); Comparisons: 8 (12.9)
| | | | | | Diff between groups (P = NS)
| | | | | | Substance abuse:
| | | | | | Patients: 0 (0); Comparisons: 2 (3.2)
| | | | | | Diff between groups (P = NS)
| | | | | | Antisocial personality disorder:
| | | | | | Patients: 0 (0); Comparisons: 2 (3.2)
| | | | | | Diff between groups (P = NS)
| | | | | | Gambling:
| | | | | | Patients: 0 (0); Comparisons: 1 (1.6)
| | | | | | Diff between groups (P = NS)
| | | | | | Homosexuality:
| | | | | | Patients: 0 (0); Comparisons: 1 (1.6)
| | | | | | Diff between groups (P = NS)
| | | | | | Affective disorders:
| | | | | | No-ED group better than normal weight bulimics (P = 0.003).
| | | | | | Dysthymia:
| | | | | | No-ED group better than normal weight bulimics (P = 0.02).
Authors, yr: | To investigate the intermediate to long-term outcome of adolescent onset AN in a group referred to child and adolescent psychiatric services. | Inclusion: | Mean Age at tx start | Score: | Study Methods: | Descriptive Results:
Halvorsen, Anderson, and Heyerdahl, 2004 | | Females | (SD) 14.9 (1.7) yrs | Fair | Demographic and tx data obtained retrospectively from med. records. | Outcomes:
Design: | | DSM IV for AN | Range: 9.2–17.8 | Method of dx: | 3 experienced specialist conducted semi-structured interviews and patients completed questionnaire packets. Patients not interviewed were interviewed by telephone and completed questionnaires. Parents were interviewed when patients unavailable. | No ED at FU: 42 (82%)
Case series | | Referred by a physician and accept for tx at Buskerud Hospital | Sex: | DSM IV criteria for AN, BN, EDNOS from EDE info and body wt. 3 experienced specialists conducted interviews. | Interviews: | AN: 1 (2%)
Comparison Group: | | Exclusion: | Female 100% | Where no interview, questionnaire and telephone interview with patient or parent | - Eating Disorder Examination; - Mini International Neuropsychiatric Interview; - Yale-Brown Obsessive Compulsive Scale; - Global Assessment of Functioning | BN: 1 (2%)
No | | None stated | Race/ethnicity: | Funding | Questionnaires | EDNOS: 7 (14%)
Location: | | Recruitment: | NR | Norwegian Research Council, the Norwegian Foundation for Health and Rehabilitation, the Regional Centre for Child and Adol Psychiatry, Regions East and South, and Buskerud Hospital. | - Eating Disorder Inventory (EDI); - Overall Life Satisfaction | Deaths: 0
Drammen, Norway | | Females who where dx'ed with AN and admitted to Child and Adol Psychiatry program at Buskerud Hospital from 1986-1998. These former patients contacted to participate in FU study. | Mean BMI (kg/cm ^ 2 ^ ) at tx start (SD) | | Statistical Methods: | M-R Scale
Yrs followed: | | Sample size: | 15.1 (1.5) | | ANOVA and t-tests | Good: N = 40 (80%)
8.8 (3.4) | | Initial sample: | Mean wt loss at tx start (SD) | | Wilcoxon (Mann-Whitney) | Intermediate: N = 8 (16%)
(3.5–14.5) | | (N = 55) | 23.2% (8.2) | | Tukey HSD | Poor: N = 2 (4%)
| | Reasons for loss to FU: | Mean wt loss at tx start corrected for increase in ht. (SD) | | Chi-Square | Psychiatric dx at FU:
| | Refusal to participate (N = 4) | 24.4% (7.7) | | Pearson's correlations | No dx including no ED N = 28 (55%)
| | Analysis sample: | Duration of sx before tx start (SD) | | Outcomes | No dx excluding ED: N = 31 (61%)
| | (N = 51) | 11.2 (6.7) mos | | Recovered = no DSM IV dx for AN, BN, EDNOS based on EDE and wt. Where EDE not administered, dx based on telephone and questionnaires. | Depression: N = 11 (22%)
| | Interviewed (N = 47) | Age onset (SD) | | M-R general outcome | Anxiety (not OCD): N = 13 (27%)
| | Patients complete questionnaire: | 14.0 (1.7) yrs | | - Good - within 15% of ABW and normal menstruation; - Intermediate - wt below 15% of ABW or menstrual irregular; - Poor - wt below 15% ABW, menstruation absent or nearly absent, or BN | OCD: N = 1 (2%)
| | (N = 2) | Range: 8.2–16.8 | | | Post-traumatic stress disorder: N = 5 (10%)
| | Parents complete questionnaire (N = 2) | Lowest BMI during tx (kg/cm ^ 2 ^ ) (SD) | | | Tourettes: N = 1 (2%)
| | | 14.8 (1.6) | | | Diff in psychiatric dx between patients with and without ED at FU:
| | | Onset prior to menarche: | | | No DSM dx (excluding ED) (P = NS)
| | | 24% | | | Two or more dx: No ED at FU: 13%, ED at FU: 56% (P = 0.004)
| | | Vomit before or during tx: | | | Depression: No ED at FU: 13%, ED at FU: 67% (P < 0.001)
| | | 28% | | | Anxiety disorder (except OCD): No ED at FU: 20%, ED at FU: 56% (P = 0.047)
| | | SES background | | | OCD (P = NS)
| | | Upper: 16 (31%) | | | Post-traumatic stress disorder (P = NS)
| | | Middle: 22 (43%) | | | Dissociative disorder (P = NS)
| | | Lower: 13 (25%) | | | Psychosis (P = NS)
| | | Age at FU | | | Tourettes (P = NS)
| | | 23.8 (3.4) yrs | | | GAF-S >80: Very good functioning: No ED at FU: 48%, ED at FU: 0 (P = 0.008)
| | | Patients in family tx | | | GAF-F >80: Very good functioning: No ED at FU: 65%, ED at FU: 0 (P = 0.001
| | | 51 (100%) | | | GAF-S Mod to severe problems: No ED at FU: 8%, ED at FU: 67% (P < 0.001)
| | | Patients in ind. psychotx. | | | GAF-F Mod to severe problems (P = NS)
| | | 17 (33%) | | | Hx of suicide ideation (P = NS)
| | | Pt hospitalized in pediatric ward: | | | Hx of suicide attempts (P = NS)
| | | 61%
Authors, yr: | To investigate whether AN patients with a low BMI at referral have low BMI at long-term FU | Inclusion: | Mean Age at referral: | Score: | Study Methods | Descriptive Results
Hebebrand et al., 1997 | | DSM III-R AN, female | 16.7 (4.5) | Fair | Record review | Correlation between BMI at referral and FU: r = 0.33 (P < 0.00001)
Design: | | Exclusion: | Range: | Method of dx: | Statistical Methods | BMI at FU, mean (SD) (range):
Case series | | 24 males, 7 females with additional somatic diseases at referral, 7 females pretreated whose BMI at referral were > 17.5 kg/m^2^ | 10–42 | DSM III-R | Corrected for multiple U tests | BMI < 13 at referral
Comparison Group: | | Recruitment: | Mean Age at FU: | Funding | Post hoc U; chi-square | 18 (3.4) (9.5 – 25.3)
No | | Composite of 5 study cohorts with a total of 341 consecutively ascertained inpatients with AN. | 26.2 (6.9) | Deutsche Forschungsgemeinschaft | Fisher's exact test | BMI at FU, mean (SD) (range):
Setting: | | Initial Sample size: | Range: | | Logistic regression | BMI ≥ 13 at referral:
Marburg, Germany | | N = 341 | 15–58 | | | 20.0 (2.6) (13.4 – 27.1)
Yrs followed: | | Reasons for loss to FU: | Sex: | | | Diff between groups at endpoint (P < 0.05)
Mean (SD): | | Excludes: N = 37 (see above) | Female: 100% | | | Mortality rate patients with BMI < 13 at referral: 11% (11/100 patients)
9.5 (5.3) | | Deaths: N = 12 (10 due to emaciation after a mean of 4.2 (4.0) yrs (range: 0–13) and 2 due to suicide) | Race/ethnicity: | | | Mortality rate patients ≥ 13 BMI at referral: 0.6% (1/172 patients)
Range: 0–33.6 yrs | | Other: N = 19 (Reasons NR) | NR | | | Diff between groups (P = 0.0001)
| | Analysis Sample size: | Duration of ED before referral, yrs, mean (SD) (range): | | | Multivariate Results
| | N = 272 | BMI < 13 at referral: | | | Predicting Lower BMI at FU:
| | | 2.2 (3.3) (0 – 19) | | | ≤17.5 or > 17.5 (ICD-10 criteria for dx of AN)
| | | BMI ≥ 13 at referral: | | | BMI at referral (P = 0.00002) Lower at referral predicts lower BMI at FU
| | | 1.3 (1.73) (0 – 16) | | | Age at referral (P = 0.03) Older at referral predicts lower BMI at FU
| | | Diff between groups | | | Age at FU (P = 0.007) Younger at FU predicts lower BMI at FU
| | | (P < 0.05) | | | Age at onset (P = NS)
Authors, yr: | Examine the time course structure of likelihood of first recovery periods for AN patients. | Inclusion: | Mean Age at tx intake (SD): | Score: | Treatment | Descriptive Results:
Herzog, Schellberg, and Deter, 1997 | Identify patient characteristics that influence the occurrence and timing of first recovery. | Feighner criteria for AN and, later, DSM III-R criteria. | 20.7 (4.1) | Fair | All patients had received 3 mo inpatient including individual psychotherapy with behavioral elements, psychodynamic elements, group psychotherapy, and counseling by a social worker. | Recovery:
Companion article: | | Exclusion: | Sex: | Method of dx: | Study Methods: | Greater chance of recovery in first 6 yrs than in later period
Deter and Herzog, 1994 | | None | Female: 100% | Feighner et al. (1972) criteria, confirmed using DSM III-R criteria, 6 patients diagnosed AN retrospectively. | Predictor variables, collected at admission for inpatient tx include: | Recovery sooner than 6 yrs after first tx: 50% of patients
Design: | | Recruitment: | Race/ethnicity: | Funding | Social class, duration of illness, wt, purging, vomiting, laxative abuse, glucose, calcium, phosphate, albumin, creatinine, alkaline phosphatase, and the AN Symptom Score (Deter, 1992) including psychological, social and physical subscores. | Avg. patient in sample had first recovery by 5.8 yrs.
Case Series | | Patients who received inpatient tx at Dept. of General Clinical and Psychosomatic Medicine, U of Heidelberg Medical School between 1971-1980 | NR | German Ministry of Technology and Research | FU assessments by physician or psychotherapist. | Throughout 12 yrs, likelihood of recovery remained below 0.2.
Comparison Group: | | Sample size: | Avg. length of illness prior to study inclusion (SD): | | M-R outcome criteria obtained annually from general practitioner. Records of add hospitalizations, if reported by general physician or insurance carrier, were requested. | Avg duration to first recovery:
No | | Original Sample: | 2.7 (3.9) yrs | | Statistical Methods: | Low serum ceatinine at baseline (.7 mg/dl): 3.3 yrs.
Location: | | (N = 88) (Feighner criteria) | % ABW at study inclusion (SD) | | Discrete-time Survival Analysis | Medium serum creatinine at baseline (1.1 mg/dl):6.1 yrs.
Heidelberg, Germany | | (N = 84) 4 excluded who did not meet DSM III-R criteria. | 65.2 (9.9) | | Outcomes | High serum creatinine at baseline (1.5 mg/dl): > 11 yrs.
Yrs followed: | | Reasons for loss to FU: | Mean BMI at study inclusion (kg/m2) (SD) | | M-R outcome criteria: | Multivariate Results:
11.7 (2.43) | | Death: 9 (7 due to AN complications, 2 suicides) | 13.3 (2.0) | | Good: wt normal, menstruation regular | Sig predictors of change over time in the likelihood of first recovery:
| | Unavailable for examination (no explanation given): 5 | SES at study inclusion: | | Intermediate (wt < 85% ABW or amenorrhea | Serum creatinine levels at baseline (P < 0.008) lower is better
| | Incomplete data: 1 | Lower: 45.2% | | Poor: wt < 85% ABW and amenorrhea | Purging behavior (P < 0.0049) less is better
| | Analysis Sample size: | Middle: 48.0% | | Outcome assessment made based on lowest known wt and most unfavorable menstruation status of that yr. | Purging and social ANSS interaction: (P < 0.04); less purging and fewer social disturbances is better
| | (N = 69) | Upper: 6.0% | | “First recovery” is first rating of ”Good” outcome. | Non purging patients with high or low social ANSS scores and purging patients with low social ANSS scores all had median survival time of 3.9 -5.2. Purging patients with high social ANSS had different course with only 33% having a first recovery by 11 yrs.
Author, Yr: | To assess factors associated with recovery and relapse in AN and BN | Inclusion: | Mean Age at tx intake (SD): | Score: | Study Methods: | AN Findings
Herzog et al., 1999 | | DSM III-R for AN and BN at tx intake (Participants reclassified according to DSM IV criteria during the study); anorexic and bulimic episodes not separated by a period of remission of at least 8 wks duration. | ANR: 23.9 (8.5) | Good | FU interviews generally conducted by telephone by trained interviewers. Instruments included: Eating Disorders Longitudinal Interval FU Evaluation (LIFE-EAT-II)-semi-structured | Descriptive Results
Design: | | Exclusion: | ANBP: 24.5 (5.9) | Method of dx: | Statistical Methods: | Full recovery:
Case series | | None | BN: 25.5 (6.5) | Modified version of Schedule for Affective Disorders and Schizophrenia - Lifetime version | Survival analysis, proportional hazards (Cox) regression | 33.70%
Comparison Group: | | Recruitment: | Sex: | Funding | Outcome Categories: | At 2 yrs: ANR: 8%; ANBP: 13%
No | | Women who sought tx in eating disorder programs in Boston, MA between 1987 and 1990. An additional 21 women with AN recruited in 1991. | Female: 100% | NIMH, Rubenstein Foundation, Harvard Eating Disorders Center | Full recovery (absence of symptoms or presence of only residual symptoms for at least 8 consecutive wks) at some point over 90 mos | At 7 yrs: ANR: 34%; ANBP: 32%
Location: | | Sample size | Race/ethnicity: | | Partial recovery (reduction of symptoms to < full recovery for ≥ 8 consecutive wks | Partial recovery:
Boston, MA, USA | | Initial Sample size: | NR | | | 83.70%
Yrs followed: | | ANR: 51 | Age at ED onset (SD): | | | At 2 yrs: ANR: 61%; ANBP: 67%
Median = 7.5; interviews conducted every 6 mos for 11 yrs | | ANBP: 85 | ANR: 17.5 (6.1) | | | At 7 yrs: ANR: 83%; ANBP: 82%
| | BN: 110 | ANBP: 16.9 (4.7) | | | Median time to partial recovery (wks):
| | Reasons for loss to FU: | BN: 19.4 (5.8) | | | ANR: 78; ANBP: 53
| | Drop outs: 17 | Proportion ABW: | | | Diff ANR and ANBP (P = NS)
| | Died (dx group and reasons NR): 7 | ANR: 0.73 (0.09) | | | Relapse after full recovery:
| | Analysis Sample size: | ANBP: 0.82 (0.10) | | | 40%
| | NR | BN: 1.03 (0.15) | | | No remission through yr 7:
| | | Lifetime hx major depression: | | | ANR: 17%
| | | ANR: 64.7% | | | ANBP: 18%
| | | ANBP: 71.3% | | | Multivariate Results
| | | BN: 60.7% | | | Sig predictors of time to full recovery (adjusted):
| | | Lifetime hx Axis I: | | | Percent of ABW at intake: HM = 250.1, 95% CI (6.90–9.066) heavier is better
| | | ANR: 62.7% | | | Duration of intake episode: HM = 0.89, 95% CI (0.81–0.96), shorter is better
| | | ANBP: 78.1% | | | Sig predictors of time to partial recovery (adjusted):
| | | BN: 74.1% | | | Duration of intake episode: HM = 0.63, 95% CI (0.45–0.87) Shorter is better
| | | Lifetime hx Axis II: | | | Percent ABW at intake: HM = 18.89, 95% CI (0.32–1.105) Higher is better
| | | ANR: 25.5% | | | Hx of hospitalization: HM = 29.60, 95% CI (1.11–791.21) Fewer hospitalizations is better
| | | ANBP: 37.9% | | | Hx of major depression: HM = 1.64, 95% CI (1.07–2.51) Not having major depression is better
| | | BN: 23.2% | | | Duration of intake episode x proportion ABW: HM = 1.65, 95% CI (1.10–2.47); ABW values >93% and shorter intake episode is better than ABW < 93% and longer duration of intake episode
| | | Lifetime hx substance use disorder: | | | Percent ABW x hx of hospitalization: HM = 0.007, 95% CI (0.0001–0.44); ABW values ≤ 69% and having hx of hospitalization is better than ABW > 69% and no hx of hospiatlization
| | | ANR: 5.9% | | | BN Findings
| | | ANBP: 16.1% | | | Descriptive Results
| | | BN: 12.3% | | | Full recovery:
| | | Duration intake episode: | | | 73.80%
| | | ANR: 6.4 (6.7) | | | At 2 yrs: BN: 53%
| | | ANBP: 7.6 (5.4) | | | At 7 yrs: BN 73%
| | | BN: 6.1 (6.3) | | | Partial recovery:
| | | | | | 99.0%
| | | | | | At 2 yrs: BN: 88%
| | | | | | At 7 yrs: BN: 98%
| | | | | | Median time to partial recovery (wks): BN: 14
| | | | | | Relapse after full recovery:
| | | | | | 35.3%
| | | | | | Multivariate Results
| | | | | | Sig predictors of time to full recovery: none identified
| | | | | | Sig predictors of time to partial recovery: none identified
Authors, yr: | Examine relationship between laboratory findings and AN disease outcomes | Inclusion: | Mean Age at tx intake (SD): | Score: | Treatment | Descriptive Results:
Herzog et al., 1997 | | Feighner criteria for AN and, later, DSM III-R criteria. | 20.7 (6.0) | Poor | All patients had received 3 mo inpatient including individual psychotherapy with behavioral elements, psychodynamic elements, group psychotherapy, and counseling by a social worker. | M-R outcome at FU:
Design: | | Exclusion: | Range: 15–36 | Method of dx: | Study Methods: | Good: 47%
Case Series | | None | Mean Age at FU (SD): | Feighner et al. (1972) criteria, confirmed using DSM III-R criteria, method of making determination not reported | FU exam on patients who received inpatient tx. Baseline is records at first admission. | Intermediate: 27%
Comparison Group: | | Recruitment: | 32.2 yrs | Medical comorbidity was ICD-9 criteria | FU assessments by physician or psychotherapist at U. of Heidelberg Med Clinic. | Poor: 14%
No | | Patients who received inpatient tx at U of Heidelberg Medical School between 1971-1980 | Sex: | Funding | FU included 1) past and present histories, lab exam, physical exam, and bone mineral density 2)standardized and open interviews re course of illness 3) discharge letters of all inpatient tx btween tx and FU. | Death:12%
Location: | | Sample size: | Female: 100% | German Ministry of Technology and Research | M-R outcome criteria obtained annually from general practitioner. Records of add hospitalizations, if reported by general physician. | Mean ABW:
Germany | | Original Sample: | Race/ethnicity: | | Statistical Methods: | Baseline: 65%
Yrs followed: | | (N = 84) met Feighner and DSM III-R criteria for AN. | NR | | Wilcoxon signed rank test | FU: 87%
11.9 | | Reasons for loss to FU: | % ABW at study inclusion (SD) | | Students t-test | Mean BMI:
Range: 9–18 | | Missing lab data: 9 | 65.2 (9.9) | | Discriminant Analysis of T0 data | Baseline: 13.7; FU: 19.3
| | Refused to participate: 9 | | | Multiple linear regression analysis | BN (DSM III-R) at FU: 16%
| | Analysis Sample size: | | | Outcomes | Diff in baseline lab findings by M-R scale outcomes (good/intermediate vs poor/deceased):
| | (N = 66) | | | M-R outcome criteria: | Albumin (P = 0.004) Poor/deceased lower
| | | | | Good: wt normal, menstruation regular | Uric acid (P = 0.02) Poor/deceased higher
| | | | | Intermediate (wt < 85% ABW or amenorrhea | Potassium (P = 0.03) Poor/deceased lower
| | | | | Poor: wt < 85% ABW and amenorrhea | Creatinine (P = 0.04) Poor/deceased higher
| | | | | Chronicity Score: sum of outcome categories of every yr. | Diff in having at least 1 comorbidity by M-R scale outcome categories (good/intermediate vs poor/deceased)
| | | | | Underwt Score: index of underwt x time. | Poor/deceased: 67%
| | | | | | Good/intermediate: 27%
| | | | | | Age matched German females: 8%
| | | | | | Mortality (N = 8):
| | | | | | SMR: 9.6
| | | | | | Mean age of death: 29 yrs
| | | | | | Mean duration of AN: 9 yrs (range 1–14) with death avg 4.2 (0–13) yrs after first presentation.
| | | | | | All met DSM III-R of AN at death, Severe purging (N = 7). BMI < 11: N = 5. Suicide: N = 1.
| | | | | | Lab predictors of death and chronicity
| | | | | | Low serum albumin at baseline: OR = 4.7, 95% CI (1.1 – 20.2)
| | | | | | Discriminant Analyses btwn surviving and deceased patients showed baseline albumin (P < 0.0001) and wt (P = 0.011) discriminated best, correctly classifying 88% of deceased and 86% of surviving patients. Adding age onset, duration at first presentation, freq. vomit and lax, social class, social or psych of ANSS did not improve model.
| | | | | | Multivariate Analysis
| | | | | | Baseline predictors of chronicity in step-wise model:
| | | | | | Creatinine (P < 0.0001)
| | | | | | Albumin (P = 0.024)
| | | | | | Glucose levels (P = 0.04)
Authors, yr: | To assess the rates of recovery for restrictor and bulimic anorexics to determine whether bulimic behavior sig affects the course of AN. To assess possible subtypes of BN based on the presence or absence of a hx of AN. | Inclusion: | Age, mean (SD) (range), yrs | Score: | Study Methods | Descriptive Results
Herzog et al., 1996 | | DSM III-R criteria for BN and or AN | 24.5 (6.7) | Good | FU interviews conducted every 3 mos. Anniversary (12, 24, 36 mo) FUs conducted in person whenever possible. | % at least partially recovered:
Design: | | Exclusion: | ANR: 21 (18 – 27) | Method of dx: | Full recovery: asymptomatic (Psychiatric Status Rating PSR < 3) for at least 8 consecutive wks. | BN: 91%
Case series | | NR | ANBP: 22 (19 – 25) | Semi-structured interview (Schedule for Affective Disorders and Schizophrenia-Lifetime Version modified to include diagnostic criteria for DSM III-R eating disorders derived from the Diagnostic Interview Schedule). | Partial recovery: maintaining for at least 8 consecutive wks a PSR level of 3 or 4. Do not meet full criteria for AN or BN but still experience sig symptomatology. | Trend (P < 0.01)
Comparison Group: | | Recruitment: | BNSAN: 25 (21 – 29) | Eating Disorders Longitudinal FU Evaluation. | Analytic Strategy | % fully recovered:
No | | Participants who sought evaluation for an eating disorder at the Massachusetts General Hospital Eating Disorders Unit and at other Boston-area eating disorders programs between 10/87 and 6/90. | BNPAN: 23 (20 – 27) | Funding | Fisher's Exact Test and Wilcoxon Rank Sum Test | BN: 62%
Location: | | Sample size: | BN: 24 (20 – 30) | NIMH, Rubenstein Foundation, Eli Lilly and Co, The Boston Obesity, Nutrition Research Center | Kaplan-Meier survival method for probability of recovery. | Trend (P < 0.01)
Boston, MA | | Initial sample: | Diff between groups (P = NS) | | Cox proportional hazards models to identify prognostic factors | Multivariate Results
Yrs followed: | | Telephone Screen: N = 554 | Sex: | | | BN Predictors of recovery; Adjusted for duration of the current episode (N = 150):
4 | | Met criteria: N = 268 | Female: 100% | | | Duration of current episode (P = NS)
| | Participated: N = 229 | Race/ethnicity: | | | Age at onset of eating disorder (P = NS)
| | Drop out: N = 4 | NR | | | Age at onset of first eating disorder (P = NS)
| | Analysis sample: | Age at onset of first disorder, mean (range), yrs | | | Current disorders involving a lack of impulse control (P = NS)
| | N = 225 | ANR: 17 (15 – 20) | | | Wt < 90% of ideal (P = NS)
| | ANR (AN and no regular bingeing or purging): N = 39 | ANBP: 17 (15 – 19) | | | Bingeing frequency (P = NS)
| | ANBP (AN and regularly engage in bingeing or purging): N = 37 | BNSAN: 17 (14 – 19) | | | Purging frequency (P = NS)
| | BNPAN (BN now and hx of AN): N = 28 | BNPAN: 16 (15 – 18) | | | Current depression (P = NS)
| | BNSAN (BN now, underwt at intake and do not meet full criteria for AN): N = 36 | BN: 18 (16 – 20) | | | Personality disorder (P = NS)
| | BN (BN with no prior hx of AN): N = 89 | Diff between groups (P = NS) | | | Any current Axis I disorder (P = NS)
| | | % attempted suicide: | | | AN Predictors of recovery: Adjusted for duration of the current episode (N = 75):
| | | ANR: 18 | | | Duration of current episode: RR = 0.50, 95% CI (0.27 – 0.94)
| | | ANBP: 33 | | | Age at onset of eating disorder (P = NS)
| | | BNSAN: 53 | | | Age at onset of first eating disorder (P = NS)
| | | BNPAN: 19 | | | Current disorders involving a lack of impulse control (P = NS)
| | | BN: 28 | | | Bulimic behaviors (P = NS)
| | | Diff between groups BNSAN had higher rates of suicide attempts versus BN and BNPAN (P < 0.001) | | | Current depression (P = NS)
| | | | | | Any current Axis I disorder (P = NS)
Authors, yr: | To assess rates and causes of death for a cohort of women with AN or BN and provide descriptive information on their ED and comorbid dx. | Inclusion: | Mean Age | Score: | Study Methods | Descriptive findings:
Herzog et al., 2000 | | Initially, meeting DSM III-R criteria for AN, AN/BN, or BN; Subsequently, using DSM IV definitions, met criteria for AN-R, ANBP, or BN. | NR | Fair | Data on mortality collected as part of a longitudinal study of AN and BN. Other data sources included death certificates, autopsy reports, relative interviews, and a National Death Index search. | AN
Design: | | Exclusion: | Sex: | Method of dx: | The Eating Disorders Longitudinal FU Evaluation (LIFE-EAT II) was administered to subjects at 6-mo intervals. General information regarding subjects' functioning in the mos prior to death was obtained by interviewing a family member. | At 11th yr FU: # of AN deaths: 7 (Crude mortality rate = 5.1%, 7 / 136) 3 subjects committed suicide.
Case series | | None | Female: 100% | SADS-L modified to include diagnostic criteria for DSM III-R as well as psychiatric hx, later updated to DSM IV criteria | | SMR indicates a sigly raised mortality rate for death at 9.6 times the expected rate (P = 0.001), 95% CI (3.86 -19.8) and for suicide at 58.1times the expected rate (P = 0.001), 95% CI (11.7 -169.7).
Comparison Group: | | Recruitment: | Race/ethnicity: | Funding | | Characteristics of deceased participants:
No | | Between October 1987 and June 1990, tx seekers at Massachusetts General Hospital. 556 recruited. | NR | NIMH ROI Grant, sponsor: Rubenstein Foundation and Harvard Eating Disorders Center. | | - At intake, 5 met ANBP dx: 2 met full AN and BN criteria; 2 met full AN criteria with BN sx; 1 met full BN criteria with AN sx.; - Ages: 24–46 yrs.; - Yrs ill at death: 9–28; - 2 met ANR criteria at intake, but later exhibited BN sx; - At time of death, of the 5 ANBP participants, 2 were classified as ANBP, 2 met AN-partial recovery criteria, 1 met AN-full recovery criteria.; - All had a hx of comorbid Axis I disorders: most common dx was alcoholism. Other comorbid disorders included bipolar disorder major depressive disorder and drug abuse.; - All participated in multiple types of tx: both individual psychotherapy and pharmacotherapy; - Hospitalized at least once: N = 6; - Participated in group therapy: N = 6; - Nutritional counseling: N = 5; - Participated in family therapy: N = 4; - All 3 subjects who committed suicide had reported suicidal ideation and 2 subjects had made at least one prior suicide attempt.
Location: | | Sample Size: | Mean duration of illness: | | | BN
Boston, MA, USA | | Using DSM IV criteria, participants classified as AN-R (N = 51), ANBP (N = 85), and BN (N = 110) status | 7.2 yrs | | | At 11th yr FU, # of BN deaths: 0
Yrs followed: | | Reasons for loss to FU:
11 | | NR
Authors, yr: | To assess the time to death and time to first relapse in a group of consecutively treated AN patients between 1960-1976 utilizing survival analytic procedures | Inclusion: | Mean Age, yrs (range): | Score: | Study Methods | Descriptive Findings
Isager et al., 1985 | | Dx of AN by the following criteria: | At primary contact: 19.0 (8–43) | Fair | FU data obtained by direct semistructured interview of 80% of the original cohort (N = 114). Hospital records, the National Registry of Patients, the Central Persons Registry, and the Registry of Causes of Death used to assess patient relapse and mortality. | Deceased Patients
Design: | | Wt loss via reduced food intake, vomiting or excessive activity; Amenorrhea (if reproductive age); Distorted body image; clinical picture not explained by other somatic or psychiatric illness | At onset of AN: | Method of dx: | Statistical Methods | Total Sample (N = 9): 6%
Case series | | Exclusion: | 16.6 (7–41) | Review of records by authors to meet the diagnostic inclusion criteria | Survival probability curves for time to first relapse and time to death were calculated. | Previous Hospitalization (N = 6): 30% (30 per 1000 per yr)
Comparison Group: | | Inpatient < 1 wk or < 2 outpatient visits; Other somatic dx (e.g., ulcer, psychosis) | Sex: | Funding | Outcome measure | Nonhospitalized (N = 3): 2% (2 per 1000 per yr)
No | | Recruitment: | Female: 93% | The Danish Medical Council; The Gangsted-Rasmussen Fonde af; the Enkefru C. Hermansens Mindelegat and the Petra Slettens Fond | Relapse: lost 15% or more of wt gained during course of tx within a yr's time (i.e., wt = 50 kg or less). | Diff between groups (P < 0.001)
Location: | | Patients who made first contact with a university hospital in Copenhagen for AN tx between 1960-1976. | Race/ethnicity: | | | Remission Rate by End of Primary Contact (N = 120):
Copenhagen, Denmark | | Review of all hospital records with a dx of AN from three departments at Rigshospital, University of Copenhagen, Child Psychiatry, Psychiatry, and Internal Medicine. | NR | | | 80%
Mean Yrs followed: | | Sample size: | Mean Duration of Illness, yrs (range): | | | Relapse Rates During FU (N = 120):
12.5 (range = 4–22) | | 151 (142 living: 114 contacted via direct semistructured interview; information about the remaining patients was obtained via hospital records and from official Danish registers) | 2.4 (0.1–15) | | | First yr: N = 17 (14% hazard rate)
| | Loss to FU Reasons: | Previous Hospitalizations for AN (%): | | | Second yr: N = 4 (4% hazard rate)
| | Death: N = 9 (N = 6 from suicide; N = 2 from AN complications; N = 1 who was severely underwt with probable suicide) | 65% | | | Third-Tenth yr: N = 1–3 per yr (hazard rate NR)
| | | Females, onset of AN before Menarche: | | | Total FU period: 3% avg annual hazard rate
| | | 18% | | | Duration of therapeutic contact < 1 yr (N = 75): 4% per yr hazard rate
| | | Mean Wt at primary contact, kgs (range): | | | Duration of therapeutic contact > or = 1 yr (N = 45): 2% per yr hazard rate
| | | 36.8 (19–60) | | | Diff between groups based on therapeutic contact (P < 0.05)
| | | % ABW at primary contact (range):
| | | 68% (40–102)
| | | Bulimia:
| | | 28%
| | | Vomiting:
| | | 41%
| | | Duration of primary contact, mos (range):
| | | 12 (0.3–76)
Authors, yr: | To assess and compare the prevalence and course of depressive disorders in a sample of adolescents with and without AN at baseline over a 10-yr period. | Inclusion: | Mean Age at Baseline, yrs (SD): | Score: | Study Methods | Descriptive Findings
Ivarsson et al., 2000 | | Cases: | AN: 16.1 (NR) | Good | All participants initially underwent a thorough psychiatric interview at baseline, a standardized clinical interview at age 21 and again at age 24 to assess current and lifetime hx of eating disorders and depressive disorders. Family hx of depressive disorders in first degree relatives also obtained. Dx made in person-N = 102 for first FU, N = 99 for second FU; by phone for second FU, N = 3 | Lifetime Prevalence of Depressive Disorder:
Companion article: | | DSM III-R or DSM IV criteria for AN | Comparisons: | Method of dx: | Participants who did not meet diagnostic criteria for an eating disorder were categorized as “no ED”. The same categorization strategy was used to classify those who did not meet diagnostic criteria for a depressive disorder (i.e., major depression, dysthymia, or bipolar disorder). | AN: 84%
Nilsson et al., 1999 | | Born 1970 or later | 16.0 (NR) | At baseline evaluation, clinical dx made via a psychiatric interview based on DSM III-R criteria | The timeframes for assessing FU outcomes are: | Comparisons: 18%
Råstam, Gillberg and Gillberg, 1995 | | AN onset < 18 yrs old | Age at 5-yr FU: | Current and Lifetime prevalence of eating disorder, depressive disorder, and other Axis I dx made using SCID-P, DSM III-R version via record review of initial interviews at baseline and via clinical interview at FU | “outcome 2” = assessment of current and lifetime hx of ED or Depressive Disorder between baseline and age 21 | (P < 0.001)
Wentz et al., 2001 | | Comparisons: | 21 | Funding | “outcome 3” = assessment of current and lifetime hx of ED or Depressive Disorder between age 21 and age 24 | Rate of Depressive Disorder prior to AN:
Wentz et al., 2000 | | No eating disorder dx, matched to cases on age, sex, school | Age at 10-yr FU: | None reported | Statistical Analyses | AN: 2%
Design: | | Exclusion: | 24 | | Chi-square tests, Fisher's exact test, and McNemar tests to evaluate and compare linear associations between dichotomous variables. | Comparisons: 4%
Prospective cohort | | Cases: | Mean Age of Onset of AN, yrs (SD): | | Backward stepwise multivariate logistic regression to assess risk of depressive disorder over time, controlling for diagnostic group status. | (P = NS)
Comparison Group: | | None | 14.3 (NR) | | | Rate of Depressive Disorder by FU Period:
Yes | | Comparisons: | Sex: | | | Outcome 2: AN: 57%
Location: | | None | Female: 94% | | | Outcome 3: NR
Göteberg, Sweden | | Recruitment: | Race/ethnicity: | | | Stability of Depressive Disorder between FU Periods:
Yrs followed: | | Cases: From total population of Göteburg, Sweden, born in 1970 and developing AN before age 18; pooled with second population screening sample reported by school and hospital health care workers during FU. Some clinically referred and some screened through school nurses and doctors, pediatricians, and child psychiatrists | NR | | | Baseline-Outcome 2 (P = NS)
10 (1985-1996) | | Comparisons: | | | | Outcome 2-Outcome 3 (P < 0.05)
| | Same schools as AN group | | | | Number of Periods of Lifetime Dx of Depressive Disorder (N):
| | selected by the school nurse | | | | 0: AN (8) Comparisons (42)
| | Sample size: | | | | 1: AN (18) Comparisons (6)
| | AN: N = 51 | | | | 2: AN (18) Comparisons (3)
| | Comparisons: N = 51 | | | | 3: AN (7) Comparisons (0)
| | Reasons for loss to FU: | | | | (P < 0.0001) AN > Comparisons
| | No attrition reported | | | | Types of Depressive Disorder in AN and Comparisons (N):
| | | | | | None: AN (8), Comparisons (42)
| | | | | | Dysthymia: AN (9) Comparisons (2)
| | | | | | MDD: AN (28) Comparisons (6)
| | | | | | Double Depression: AN (3) Comparisons (0)
| | | | | | Bipolar Disorder: AN (3) Comparisons (1)
| | | | | | (P < 0.0001) AN > Comparisons
| | | | | | Rates of Depressive Disorder by ED status at Outcome 3, N (%):
| | | | | | No ED /No Depressive Disorder (77): 84.6%
| | | | | | No ED/Depressive Disorder (14): 15.4%
| | | | | | ED/No Depressive Disorder (3): 27.2%
| | | | | | ED/Depressive Disorder (8): 72.8%
| | | | | | (P < 0.0001) Lower rates of Depressive Disorder in resolved ED
| | | | | | Rates of Familial Depressive Disorder by Participant Depressive Disorder Status:
| | | | | | (P = NR)
| | | | | | Multivariate Results
| | | | | | Predictors of Depressive Disorder at Outcome 2:
| | | | | | Diagnostic Group (P < 0.00001), OR = 7.7, 95% CI (3.0 to 19.6)
| | | | | | Depressive Disorder at Baseline (I = NS)
| | | | | | Family Hx of Depressive Disorder (P = NS)
| | | | | | Predictors of Depressive Disorder at Outcome 3:
| | | | | | Diagnostic Group (P < 0.05), OR = 4.03, 95% CI (1.15 to 14.19)
| | | | | | Depressive Disorder at Outcome 2 (P < 0.05), OR = 3.17 (1.05 to 9.58)
| | | | | | Family Hx of Depressive Disorder (P = NS)
Authors, yr: | To determine mortality ratios and predictors of fatal outcome in women dx with AN or BN. | Inclusion: | Mean Age | Score: | Study Methods | Descriptive
Keel et al., 2003 | | (1) DSM III-R dx of AN or BN retrospectively (2) female (3) min age of 12 yrs (4) residence within 200 miles of Boston (5) English speaking, and (6) no evidence of organic brain syndrome or terminal illness. | NR | Fair | During FU interviews, the Longitudinal Interval FU Evaluation adapted for EDs used to assess ED and comorbid psychiatric disorders. Course of disorder coded on a wk-by-wk basis using PSR. Social adjustment evaluated on a 5-point scale. GAF used to evaluate overall level of symptom severity from all disorders and psychosocial function. Social adjustment, GAF scores, and tx rated on a wk-by-wk basis throughout FU. Interviews conducted, in person when possible, every 6 to 12 mos. | Number of Deaths:
Design: | | Exclusion: | Sex: | Method of dx: | FU telephone calls conducted to determine vital status for all longitudinal study participants as of October 2000. | 11 (4.5%)
Case series | | None | Female: 100% | Structured diagnostic interview | Statistical Methods | AN: 10
Comparison Group: | | Recruitment: | Race/ethnicity: | Funding | Crude mortality rates and SMRs calculated. Expected number of deaths derived from US decennial life tables for 1989-1991. Expected number of suicides derived from 1995 Annual Report: Vital Statistics of Massachusetts. | ANR: 5
No | | 294 women recruited for participation in a prospective longitudinal study between January 1, 1987, and December 31, 1991. Virtually all seeking outpatient tx for their Ed at the Massachusetts General Hospital Eating Disorders Unit or other Boston area eating disorder programs (37% received inpatient). | NR | NIMH; Eli Lily and Co.; Rubenstein Foundation; Harvard Eating Disorders Center | Cox regression models used to determine predictors of fatal outcome. Multivariate regression model used to predict death. | ANBP: 5
Location: | | Sample size: | | | | Diff by subtype (P = NS)
Boston, Mass | | N = 294 met study criteria | | | | BN: 1
Yrs followed: | | N = 250 agreed to participate | | | | Crude mortality:
MeAN: 8.6 | | N = 246 randomized and participated (4 dropped out after intake interview) | | | | AN: 7.4%
MediAN: 9 | | Retrospectively application of DSM IV criteria: | | | | BN: 0.9%
| | Met AN criteria: N = 136 | | | | SMR
| | Met BN criteria: N = 110 | | | | AN: 11.6; 95% CI (5.5–21.3)
| | | | | | BN: 1.3; 95% CI (0.0–7.2)
| | | | | | Mortality rates elevated in AN but not BN
| | | | | | Cause of death
| | | | | | ANBP: Pneumonia
| | | | | | ANR (N = 3) Suicide
| | | | | | ANBP: Cardiac dysrythmia
| | | | | | ANBP: Alcohol poisoning
| | | | | | ANBP: Diabetes mellitus
| | | | | | BN: Mitral valve prolapse
| | | | | | ANR: Amyotrophic lateral sclerosis
| | | | | | ANBP: Suicide
| | | | | | ANR: Heart and liver failure
| | | | | | SMR associated with suicide for AN: 56.9, 95% CI (15.3–145.7), sig higher
| | | | | | Multivariate Results
| | | | | | Sig predictors of death among AN patients (controlling for age and duration of illness before intake):
| | | | | | Greater severity of alcohol use disorders (P < 0.001)
| | | | | | Greater severity of substance use disorders (P = 0.03)
| | | | | | Worse social adjustment (P = 0.02)
| | | | | | Worse GAF scores at FU (P = 0.01)
| | | | | | Using the Bonferroni-corrected P = 0.0016, only severity of alcohol use disorder remained sig.
| | | | | | Predictors of time to death among AN patients
| | | | | | Duration of illness at tx intake: HM = 1.48, 95% CI (1.11–1.99) (P = 0.001)
| | | | | | Affective disorder hospitalization at intake: HM = 0.0001, 95% CI (0.00–0.27) (P = 0.001)
| | | | | | Suicidality associated with mental illness other than ED and substance abuse: HM = 23.92, 95% CI (0.81–705.52) (P = 0.05)
| | | | | | Severity of alcohol use over course of illness: HM = 5.55, 95% CI (1.68–18.29) (P = 0.001)
Authors, yr: | To examine the relationship between control and the intermediate term outcome of Chinese patients with AN. | Inclusion: | Mean age at onset of illness: | Score: | Study Methods: | Descriptive Results
Lee et al., 2005 | | DSM III-R criteria for AN including: Typical (N = 63) and Atypical (N = 25; all criteria except “fat phobia”) | 18.1 (3.9) | Fair | Interviewer assessed M-R Outcomes, SCI | M-R Outcome:
Companion article: | | Exclusion: | Mean age at clinical presentation: | Method of dx: | Statistical Analyses: | Good: 62.2%
Lee, Chan, and Hsu, 2003 | | NR | 20.4 (5.4) | SCID, M-R Outcome Assessment Schedule | Simple t-tests, ANOVA, post-hoc Bonferroni t-test | Intermediate: 32.9%
Design: | | Recruitment: | Mean age at time of study: | Funding | Outcomes (based on avg score from M-R Outcome Assessment Schedule): | Poor: 5.3%
Case series | | Individuals contacted from January 2000-June 2001with onset of illness at least 4 yrs before study who had been seen at psychiatric and eating disorders clinics of a university-affiliated general hospital between May 1984 - June 2000. | 27.0 (6.9) | Research Grant Council, Hong Kong | Good (>8) | M-R Outcome categories in relation to SCI profile scale categories:
Comparison Group: | | Sample size: | Sex: | | Intermediate (>4 and ≤8) | Overall general sense of control (scale 1):
No | | Initial Sample size: | Female: 100% | | Poor: 0–4 | Good: 4.28 (0.70)
Location: | | N = 88 | Race/ethnicity: | | | Intermediate: 3.73 (0.89)
Hong Kong | | Reasons for loss to FU: | Chinese: 100% | | | Poor: 2.86 (0.97)
Yrs followed: | | Deaths: N = 3 (Suicide: N = 2; Emaciation: N = 1); Mortality rate 3.4%; SMR: 10.5 | BMI, before illness, mean: | | | Diff between groups (P = 0.001)
9 | | Refused to participate: N = 2 | 19.6 (2.4) | | | Good group higher sense of control than other groups
| | Alive but could not be traced: N = 3 | BMI, mean, at clinical presentation: | | | Positive sense of control (scale 2):
| | Analysis Sample size: | 14.6 (1.9) | | | Good: 4.04 (0.74)
| | N = 80 | | | | Intermediate: 3.69 (0.93)
| | Of these, 74 completed self-rated scales including: | | | | Poor: 2.95 (1.41)
| | Typical (N = 56) and Atypical (N = 18; all criteria except “fat phobia”), also categorized as Restrictive (N = 51); Bulimic (N = 23) | | | | Diff between groups (P = 0.026)
| | | | | | Good group higher pos sense of control than poor group
| | | | | | Negative sense of control (scale 3):
| | | | | | Good: 3.19 (0.99)
| | | | | | Intermediate: 4.17 (1.07)
| | | | | | Poor: 5.35 (0.53)
| | | | | | Diff between groups (P = 0.001)
| | | | | | Good group lower neg sense of control than other groups
| | | | | | Specific sense of control (scale 4):
| | | | | | Good: 4.65 (0.72)
| | | | | | Intermediate: 4.03 (0.73)
| | | | | | Poor: 3.18 (0.81)
| | | | | | Diff between groups (P = 0.001)
| | | | | | Good group higher sense of control than other groups
| | | | | | Positive assertive mode of control (scale 5):
| | | | | | Diff between groups (P = NS)
| | | | | | Positive yielding mode of control (scale 6):
| | | | | | Diff between groups (P = NS)
| | | | | | Negative assertive mode of control (scale 7):
| | | | | | Good: 2.04 (0.38)
| | | | | | Intermediate: 2.39 (0.46)
| | | | | | Poor: 2.23 (0.72)
| | | | | | Diff between groups (P = 0.007)
| | | | | | Good group lower neg assertives than other group
| | | | | | Good group less neg assertive than intermediate group
| | | | | | Negative yielding mode of control (scale 8):
| | | | | | Good: 2.10 (0.63)
| | | | | | Intermediate: 2.43 (0.52)
| | | | | | Poor: 2.95 (0.81)
| | | | | | Diff between groups (P = 0.009)
| | | | | | Good group less neg yielding than poor group
| | | | | | Desire for control (scale 9):
| | | | | | Good: 4.19 (0.80)
| | | | | | Intermediate: 4.86 (1.07)
| | | | | | Poor: 4.66 (1.37)
| | | | | | Diff between groups (P = 0.016)
| | | | | | Intermediate group higher desire for control than poor group
| | | | | | Diff between typical and atypical patients on control:
| | | | | | Typical lower sense of control in the domain of body (P = 0.033)
| | | | | | Typical lower sense of control in the domain of mind (P = 0.036)
| | | | | | Typical stronger desire for control (P = 0.014)
Authors, Yrs: | To determine intermediate-term outcomes for AN among Chinese patients in Hong Kong. | Inclusion: | Mean age (SD): | Score: | Study Methods: | Descriptive Results
Lee, Chan, and Hsu, 2003 | | DSM III-R criteria for AN including: Typical (N = 63) and Atypical (N = 25; all criteria except “fat phobia”) | 26.9 (6.7) | Fair | Interviewer assessed M-R Outcome Assessment Schedule, Hamilton Depression Rating Scale, and Structured Clinical Interview. Self-rated evaluations included EDI, EAT, EDE, 36-Item Short-Form Health Survey, SCL-90, Beck Depression Inventory, Rosenberg Self-Esteem Scale | Median duration for recovery (BMI ≥ 17.5):
Companion article: | | Exclusion: | Range: 16.2 – 47.7 | Method of dx: | Statistical Methods | 3.7 yrs, 95% CI (3.2 – 4.2)
Lee et al., 2005 | | NR | Mean onset age (SD) | SCID, M-R Outcome Assessment Schedule | Chi-Square, t-tests, ANOVA, correlation coefficients to compare diff in outcome. | 3 consecutive menstrual cycles:
Design: | | Recruitment: | 18.1 (3.8) | Funding | Outcomes (based on avg score from M-R Outcome Assessment Schedule): | 5.0 yrs, 95% CI (3.9 – 6.1)
Case series | | Onset of illness at least 4 yrs before study who had been seen at psychiatric and eating disorders clinics of a university-affiliated general hospital between May 1984 – June 2000. | Range: 11.2 – 28.0 | Research Grant Council, Hong Kong | Good (>8) | MR-Scale Outcomes
Comparison Group: | | Sample Size: | Age at clinical presentation (SD): | | Intermediate (>4 and ≤8) | (N = 74)
No | | Initial sample size: | 20.4 (5.3) | | Poor: 0–4 | Good:
Location: | | N = 88 | Range: 12.3 – 38.0 | | | Total: 61.8%
Hong Kong | | Reasons for loss to FU: | Premorbid BMI: | | | Typical: 52.6%
Yrs followed (SD): | | Deaths: N = 3 (Suicide: N = 2; Emaciation: N = 1); Mortality rate 3.4%; SMR: 10.5 | 19.6 (2.4) | | | Atypical: 89.47%
Avg 9 (5.2) after onset of illness | | Refused to participate: N = 2 | Typical: | | | Intermediate:
| | Alive but could not be traced: N = 3 | 20.1 (2.3) | | | Total: 32.9%
| | Analysis Sample size: | Atypical: | | | Typical: 42.11%
| | N = 80 | 18.5 (2.2) | | | Atypical: 5.26%
| | Of these, 74 completed self-rated scales | (P = 0.004) | | | Poor:
| | | BMI at clinical presentation: | | | Total: 5.3%
| | | 14.4 (2.0) | | | Typical: 5.26%
| | | Typical: | | | Atypical: 5.26%
| | | 14.8 (1.9) | | | Diff between typical and atypical (P = 0.006); Atypical did better
| | | Atypical: | | | ED Dx Outcomes:
| | | 13.2 (1.6) (P < 0.001) | | | No ED: N = 34
| | | Current BMI: | | | AN: N = 11
| | | 18.5 (2.8) | | | BN: N = 15
| | | Sex: | | | EDNOS: N = 14
| | | Female: 100% | | | ED Dx Outcomes:
| | | Race/ethnicity: | | | No ED:
| | | Chinese: 100% | | | Typical: 40.68%
| | | AN Subtypes: | | | Atypical: 57.14%
| | | Restrictive: 67.0% | | | BN:
| | | Bulimic: 33.0% | | | Typical: 25.42%
| | | Hospitalized: | | | Atypical: 4.76%
| | | 72% | | | EDNOS:
| | | Social Class (as defined by U.K. Registrar General's classification of paternal occupation): | | | Typical: 15.25%
| | | I: 5.7% | | | Atypical: 28.57%
| | | II: 9.1% | | | AN, restricting:
| | | III: 27.3% | | | Typical: 4 (6.78%)
| | | IV: 47.7% | | | Atypical: 9.52%
| | | V: 10.2% | | | AN, bulimic:
| | | | | | Typical: 11.86%
| | | | | | Atypical: 0.00%
| | | | | | Diff between groups (P = 0.06)
| | | | | | Never married:
| | | | | | 80%
| | | | | | Fully employed:
| | | | | | 62.5%
| | | | | | EAT-26, mean (SD):
| | | | | | Typical: 28.75 (16.94)
| | | | | | Atypical: 14.00 (8.90)
| | | | | | Diff between groups (P = 0.001)
| | | | | | Atypical better
| | | | | | EDE-Q, mean (SD):
| | | | | | Typical: 2.56 (1.53)
| | | | | | Atypical: 1.02 (0.80)
| | | | | | Diff between groups (P = 0.001)
| | | | | | Atypical better
| | | | | | EDI Drive for thinness, mean (SD):
| | | | | | Typical: 7.48 (7.00)
| | | | | | Atypical: 1.61 (3.96)
| | | | | | Diff between groups (P = 0.001)
| | | | | | Atypical better
| | | | | | EDI Bulimia, mean, SD:
| | | | | | Typical: 4.20 (5.70)
| | | | | | Atypical: 1.78 (3.06)
| | | | | | Diff between groups (P = 0.03)
| | | | | | Atypical better
Author, yr: | Examine clinical course, predictors and outcome of patients 21 yrs after first inpatient tx for AN. | Inclusion: | Mean Ae at FU (SD): | Score: | Study Methods: | Descriptive Findings
Löwe et al., 2001 | | Feighner diagnostic criteria for AN (at initial assessment) and DSM IV criteria (retrospectively) | 42.0 (6.5) | Fair | Psychiatric interview, physical examination, and standardized psychological questionnaires | Percentage of Individuals with outcome according to PSR scale:
Design: | | Exclusion: | Sex: | Method of dx: | Outcome groups defined corresponding to Psychiatric Status Rating Scale for AN (PSR): | Good: 50.6%
Case series | | No severe somatic disorders | Female: 100% | Feighner's diagnostic criteria for AN (on initial assessment) and Psychiatric Status Rating Scale for AN (at FU) | Good (full recovery): 1 | Intermediate: 20.8%
Comparison Group: | | Recruitment: | Race/ethnicity: | Funding | Intermediate (Partially recovered): 2,3,4 | Poor: 26%
No | | Patients who received inpatient tx between 1971-1980 at U Medical Hospital in Heidelberg, Germany | NR | German Ministry of Technology and Research and Medical faculty of University of Heidelberg | Poor (including mortality): 5,6 | Mean BMI by PSR scale outcome groups (SD):
Location: | | Sample size: | Mean BMI at FU (SD): | | Statistical Methods | Good: 21.6 (2.3)
Germany | | Initial sample: | 20.2 (3.1) | | Subjects-yrs method (to calculate mortality), ANOVA, Fischer's exact tests, paired t-tests, ordered logistic regressions. | Intermediate: 19.7 (2.1)
Yrs followed: | | 84 participants evaluated at 3.6 and 11.7 yr FU | Marital Status: | | | Poor: 15.3 (2.7)
Mean (SD) = 21.3 (2.9) | | Reasons for loss to FU: | Never married: 17.5% | | | Diff between groups (P < 0.001)
| | Deceased N = 14 (12 directly due to AN), could not contact or refused, N = 7. | Divorced/separated/widowed: 11.1% | | | GAF scores by PSR scale outcome groups (SD):
| | Analysis sample:N = 63 | Married/living with partner: 71.4% | | | Good: 73.7% (12.2)
| | | Living arrangements: | | | Intermediate: 66.6% (14.5)
| | | Alone: 20.6% | | | Poor: 39.4% (15.2)
| | | With partner: 60.3% | | | Diff between groups (P < 0.001)
| | | With family members: 19.1% | | | Psychosocial outcomes by PSR scale outcome groups:
| | | Has children: | | | Marital status (P = NS)
| | | 68.30% | | | Living arrangement (P < 0.001) worse outcome more likely to live alone
| | | Able to work: | | | Percentage who have children (P = 0.03) Poor outcome less likely
| | | 71.40% | | | Percentage able to work (P < 0.001) worse outcome less able to work
| | | | | | Mood disorders by PSR scale outcome groups:
| | | | | | Good: 7.7%
| | | | | | Intermediate: 31.3%
| | | | | | Poor: 37.5%
| | | | | | Diff between groups (P = 0.02)
| | | | | | Anxiety disorders by PSR scale outcome groups:
| | | | | | Good 10.3%
| | | | | | Intermediate:18.8%
| | | | | | Poor: 37.5%
| | | | | | Diff between groups (P = NS)
| | | | | | Substance related disorders by PSR outcome groups:
| | | | | | Good: 5.1%
| | | | | | Intermediate: 6.3%
| | | | | | Poor: 50.0%
| | | | | | Diff between groups (P < 0.001)
| | | | | | Regression predicting PSR scale outcome at T3 FU (21 yrs from inpatient admission) based on variable values from T2 (12 yrs from inpatient admission) (each analyzed separately):
| | | | | | BMI:
| | | | | | OR = 0.68, 95% CI (0.55 - 0.84) (P < 0.001); higher is better
| | | | | | Severity of psychological symptoms:
| | | | | | OR = 1.30, 95% CI (1.16–1.47) (P < 0.001); less severe is better
| | | | | | Severity of social problems:
| | | | | | OR = 1.25, 95% CI (1.10–1.42) (P < 0.001); less severe is better
| | | | | | EDI-Ineffectiveness:
| | | | | | OR = 1.20, 95% CI (1.07–1.35) (P = 0.003); lower is better
| | | | | | EDI-Perfectionism:
| | | | | | OR = 1.18, 95% CI (1.01–1.37) (P = 0.042); lower is better
| | | | | | EDI-Interpersonal distrust:
| | | | | | OR = 1.21, 95% CI (1.03–1.44) (P = 0.023)
| | | | | | Lower is better
| | | | | | EDI-Interoceptive awareness:
| | | | | | OR = 1.16, 95% CI (1.02–1.31) (P = 0.021)
| | | | | | Lower is better
| | | | | | Haemoglobin (mmol/l):
| | | | | | OR = 0.46, 95% CI (0.23–0.91) (P = 0.025)
| | | | | | Higher is better
| | | | | | Alkaline Phosphatase:
| | | | | | OR = 1.02, 95% CI (1.01–1.04) (P = 0.013)
| | | | | | Lower is better
Authors, yr: | To assess the mortality rates of AN patients living in Denmark who were admitted for inpatient tx between 1970 and 1987 | Inclusion: | Mean Age, yrs (SD): | Score: | Study Methods | Descriptive Findings
Møller-Madsen, Nystrup, and Nielsen, 1996 | | All former AN inpatients whose data was recorded in the Danish Central Register on Psychiatric Admission between 1/1/70 and 12/31/86 with an ICD-8 AN primary or secondary dx | At First Psychiatric Admission: | Fair | Mortality status of the sample assessed through linking data obtained from Danish Central Register on Psychiatric Admission between 1970 and 1987 to information in the Danish Central Persons Registry and the Register on Causes of Death at the Danish National Health Board. Mortality status was assessed on 11/15/87. | Patient mortality:
Design: | | Exclusion: | AN as primary dx (women): 21.3 (7.5) | Method of dx: | Also reviewed from Register on Causes of Death, a list of individuals who had ICD-8 ED dx on their death certificate to evaluate the accuracy of utilizing the Danish Central Register on Psychiatric Admission for quantifying the number of persons with AN. | 60% due to AN or suicide
Case series | | None | AN as secondary dx (women): | Verification of ICD-8 AN primary or secondary dx from Danish Central Register on Psychiatric Admission; How the dx was ascertained was not reported | SMR standardized against age, sex, and period in the population from which patients were drawn. | SMR By Gender
Comparison Group: | | Recruitment: | 27.4 (12.1) | Funding | Statistical Methods | Female (N = 45 died): 9.2, 95% CI (6.7–12.3) (P < 0.001) diff from expected
No | | See inclusion criteria above | (P < 0.001) | Fru C. Hermansens Mindelegat, Snedkermester J. Wichmann og fru else Wichmann's Fond; Dansk Psykiatrisk Forskningsfond af 1967; Foundation for Research into Mental Disorders | SMRs were calculated for male and female probands separately, for age at first psychiatric admission (females only), for period of first psychiatric admission within the first five yrs (females only), and for length of FU (females only). Chi-square tests used to test for diff between observed and expected mortality for each of the above categories. | Male (N = 5 died): 8.2, 95% CI (2.7–19.1) (P < 0.001) diff from expected
Location: | | Sample size: | AN as primary dx (male): NR | | | Diff between groups (P = NS)
Denmark | | N = 853 probands identified through Danish Central Register on Psychiatric Admission during specified time period. | AN as secondary dx (male): NR | | | SMR By Length of FU in yrs (Females only; N = 790)
Mean Yrs followed: | | Reasons for loss to FU: | (P = NS) | | | < 1 (N = 14 died): 30.5, 95% CI (16.7–51.2) (P < 0.001) diff from expected
7.8 | | Death: N = 50 (N = 13 from AN complications; N = 11 from natural causes; N = 18 from suicide; N = 2 from accidents; N = 1 from unknown causes; N = 3 could not be determined in time for the analysis) | At Death: | | | 1–4 (N = 14 died): 8.6, 95% CI (4.7–14.5) (P < 0.001) diff from expected
Range: < 1–17 | | | Female (N = 45): 36 (range = 18.1–64.7) | | | 5–9 (N = 10 died): 5.9, 95% CI (2.8–10.9) (P < 0.001) diff from expected
| | | Male (N = 5): 24.5 (range = 14.2–48.1) | | | 10–14 (N = 6 died): 5.7, 95% CI (2.1–12.4) (P < 0.001) diff from expected
| | | (P = NR) | | | > or = 15 (N = 1 died): 10.5, 95% CI (0.27–58.5) (P = NS)
| | | Sex: | | | SMR By Age at First Psychiatric Admission (Females only; N = 790)
| | | Female:93% | | | < 15 (N = 0 died): NA
| | | Race/ethnicity: | | | 15–19 (N = 6 died): 6.6, 95% CI (2.4–14.4) (P < 0.001) diff from expected
| | | NR | | | 20–24 (N = 13 died): 17.5, 95% CI (9.3–29.9) (P < 0.001) diff from expected
| | | | | | 25–29 (N = 10 died): 17.0, 95% CI (8.1–31.3) (P < 0.001) diff from expected
| | | | | | 30–34 (N = 4 died): 7.7, 95% CI (2.1–19.7) (P < 0.005) diff from expected
| | | | | | > or = 35 (N = 12 died): 6.6, 95% CI (3.4–11.5)
| | | | | | (P < 0.001) diff from expected
| | | | | | SMR By Period of First Psychiatric Admission (Females only; N = 658-cases admitted)
| | | | | | 1970-1974 (N = 6 died): 11.0, 95% CI (4.03–23.9) (P < 0.001) diff from expected
| | | | | | 1975-1979 (N = 8 died): 11.3, 95% CI (4.9–22.3) (P < 0.001) diff from expected
| | | | | | 1980-1984 (N = 12 died): 18.8, 95% CI (9.7–32.8) (P < 0.001) diff from expected
| | | | | | 1970-1984 (N = 26 died): 13.8, 95% CI (8.9–20.2) (P < 0.001) diff from expected
| | | | | | Diff between periods (P = NS) No change in pattern over time
Authors, yr: | To assess both long-term outcomes and sig predictors of outcome in a group of former AN patients treated in a specialized, community-based outpatient program | Inclusion: | Age at Presentation (%): | Score: | Study Methods | Descriptive Findings
Morgan, Purgold, and Welbourne, 1983 | | Met diagnostic criteria specified by Russell (1970): endorsement of wt loss behaviors such as food avoidance, self-induced vomiting, purging, excessive exercise; presence of an endocrine disorder (i.e., amenorrhea, impotence, loss of libido); marked fear of becoming fat and a distorted judgment of body size; non-specific depressive, phobic, obsessional or hysterical symptoms may accompany other features | < 18: 35% | Fair | During the FU period, outcome information gathered directly from patient via interview (69%), directly from interviews with relative of the patient (8%), through a questionnaire sent to the patient (9%), or from other informants either directly or indirectly (14%). | Binge-eating at FU:
Design: | | Exclusion: | 18–30: 62% | Method of dx: | M-R scales used to quantify clinical outcome status at FU utilizing last 6-mos prior to FU interview as timeframe for assessment. This yielded both an avg outcome score (i.e.,, composite rating based on 12-pt scales for nutritional status, mental status, sexual adjustment, menstrual functioning, and SES, with high scores more indicative of good prognosis) and the general outcome category (i.e., based on body wt and menstrual functioning: Good = maintained ABW w/in 15% of avg norms and regular menstrual cycles; Intermediate = intermittent maintenance of ABW w/in 15% of avg norms and/or there is continued menstrual dysfunction; Poor = ABW never reached w/in 15% of avg norms and menses have been absent or sporadic. | 27%
Case series | | NR | >30: 4% | Russell (1970) criteria for AN via clinical interview at presentation and at FU | Statistical Analyses | Vomiting at FU:
Comparison Group: | | Recruitment: | Mean Age at onset of Food Difficulties, yrs (SD): | Funding | Percentages, frequencies, means, ranges, and medians | 9%
None | | Participants were a series of consecutive referrals to the Bristol Royal Infirmary AN clinic between 1973 and 1978. Approximately half had received inpatient tx. | 17.2 (3.3) | South Western Regional Health Authority Research Committee | Chi-square analyses to assess predictors of clinical outcome status at FU. | General Outcome Status Category:
Location: | | Sample size: | Sex: | | | Good: 58%
Bristol, UK | | N = 78 | Female: N = 73 | | | Intermediate: 19%
Mean Yrs followed: | | Reasons for loss to FU: | Race/ethnicity: | | | Poor: 19%
5.8 | | Death: N = 1 | NR | | | Deceased: 1%
Range (4–8.5) | | Insufficient FU info obtained: N = 4 | Social Class at Presentation (%): | | | Unknown: 3%
| | | I: 6% | | | Predictors of poorer general M-R outcome category:
| | | II: 49% | | | Greater duration of food difficulties (P < 0.05)
| | | III: 33% | | | Greater duration of amenorrhea (P = 0.029)
| | | IV: 8% | | | Family hostility towards patient (P = NS)
| | | V: 0% | | | Disturbed relationship between patient and family (P = 0.02)
| | | Marital Status at Presentation (%): | | | Personality difficulties (P = NS)
| | | Single: 87% | | | Age of onset (P = NS)
| | | Married/Divorced: 13% | | | Degree of wt loss (P = NS)
| | | Duration of Food Difficulties, yrs (%): | | | Vomiting (P = NS)
| | | < 1: 38% | | | Binge-eating (P = NS)
| | | 1–2: 17% | | | Father's social class (P = NS)
| | | 2–3: 15% | | | Neurotic/behavioral disorder at school (P = NS)
| | | 3–7: 15% | | | Previous psychological tx (P = NS)
| | | >7: 15% | | | Mental illness in nuclear family (P = NS)
| | | Median: 1.6 | | | Sibling rivalry (P = NS)
| | | Previous psych tx for AN (%): | | | Anomalous family situation (P = NS)
| | | 12% | | | Predictors of poorer avg M-R outcome scores:
| | | Lowest Mean ABW (Matched Normals (SD): | | | Greater duration of food difficulties (P < 0.01)
| | | 67.8 (8.2) | | | Duration of amenorrhea (P < 0.0042)
| | | Binge-eating at presentation: | | | Family hostility towards patient (P < 0.05)
| | | 37% | | | Disturbed relationship between patient and family (P = 0.018)
| | | Vomiting at presentation: | | | Personality difficulties (P = 0.05)
| | | 35% | | | Vomiting (P = NS)
| | | | | | Binge-eating (P = NS)
| | | | | | Father's social class (P = NS)
| | | | | | Neurotic/behavioral disorder at school (P = NS)
| | | | | | Previous psychological tx (P = NS)
| | | | | | Mental illness in nuclear family (P = NS)
| | | | | | Sibling rivalry (P = NS)
| | | | | | Anomalous family situation (P = NS)
Authors, yr: | To assess and compare the prevalence of personality disorders, obsessive-compulsive disorder and autism spectrum disorders in a group of adolescents with and without AN at baseline over a 10-yr period | Inclusion: | Mean Age at Baseline, yrs (range): | Score: | Study Methods | 10-yr FU findings
Nilsson et al., 1999 | | Cases: | AN: 16.1 (15.7–16.5) | Good | The prevalence of PD's, PDD's/Aspergers, impulsivity symptoms, obsessive compulsive symptoms and Axis I dx assessed at baseline and at 6- and 10-yr FU via standardized clinical interview methods. Participants also administered the M-R outcome scales, an alexithymia questionnaire (i.e., TAS-20) and underwent a battery of neuropsychological tests at the final FU. Clinicians rated participants for difficulties with reciprocal interactions at the 10-yr FU (e.g., mimicry, gestures, eye contact in communication, mental status). | Descriptive Results
Companion article: | | DSM III-R or DSM IV criteria for AN | Comparisons: 16.0 (15.5–16.5) | Method of dx: | Although standard interviews for DSM III-R were used to assess PD prevalence, PD's in this sample were also coded separately according to the DSM IV criteria at final FU. | Rates of Eating Disorders in AN group: 27%
Ivarsson et al., 2000 | | Born 1970 | (P = NS) | Psychiatric interview at baseline consistent with DSM III-R | Statistical Analyses | Prevalence of Tx for AN: 75%
Råstam, Gillberg and Gillberg, 1995 | | AN onset < 18 yrs old | Mean Age at AN Onset, yrs (range): | Structured, standardized clinical interviews (SCID-II, DSM III-R version) to assess for personality disorder prevalence; Pervasive developmental disorder prevalence according to DSM III-R criteria also obtained via clinical interview | Chi-square tests for matched and unmatched pairs for categorical, diagnostic status. | Mean Wt, kg (95% CI):
Wentz et al., 2001 | | Comparisons: no eating disorder dx, matched to cases on age, sex, school | 14.3 (13.9–14.7) | Structured standardized clinical interviews (SCID-I, DSM III-R version) to assess prevalence of Axis I psychiatric disorders | Two-sample t-tests performed for continuous variables (Y-BOCS and TAS-20) | AN: 62.3 (58.5–66.1)
Wentz et al., 2000 | | Exclusion: | Mean Age at FU 1, yrs: | Semi-structured interview (Schedule for the Assessment of Conduct Disorder, Hyperactivity, Anxiety Disorder, Mood Disorder, and Psychoactive Substance Abuse—CHAMPS) to evaluate prevalence of ADHD | | Comparisons: 63.7 (60.8–66.5)
Design: | | Cases: | AN: 21.0 | Structured, standardized clinical interview (SCID-II for DSM III-R) for PD dx, for Axis I dx (SCID-I for DSM III-R), for Asperger's disorder (Asperger Syndrome Diagnostic Interview), for impulsivity symptoms (CHAMPS), and the Y-BOCS for OCD at FU 2 | | (P = NS)
Prospective cohort | | None | Comparisons: 20.8 | Funding | | Mean BMI, kg/m ^ 2 ^ (95% CI):
Comparison Group: Yes | | Comparisons: | (P = NS) | NR | | AN: 22.2 (21.0–23.4)
Location: | | None | Mean Age at FU 2, yrs: | | | Comparisons: 22.2 (21.2–23.2)
Göteberg, Sweden | | Recruitment: | AN: 24.5 | | | (P = NS)
Yrs followed: | | Cases: From total population of Göteburg, Sweden, born in 1970 and developing AN before age 18; pooled with second population screening sample reported by school and hospital health care workers during FU. Some clinically referred and some screened through school nurses and doctors, pediatricians, and child psychiatrists | Comparisons: 24.2 | | | Prevalence of OCD (N):
10 (1985-1996) | | Comparisons: | (P = NS) | | | AN: 8
| | Same schools as AN group | Mean Time of AN Onset to FU 1, yrs (range): | | | Comparisons: 1
| | selected by the school nurse | 6.7 (6.3–7.0) | | | (P < 0.05) AN > Comparisons
| | Sample size: | Mean Time of AN Onset to FU 2, yrs (range): | | | Mean TAS-20:
| | Initial sample: | 10.2 (9.7–10.6) | | | AN: 42.2, 95% CI (38.7–45.9)
| | AN: N = 51 | Mean Time Between Baseline and FU 1, yrs (range): | | | Comparisons: 38.6, 95% CI (36.0–41.1)
| | Control: N = 51 | AN: 4.9 (4.7–5.2) | | | (P = NS)
| | Reasons for loss to FU: | Comparisons: 4.6 (4.3–4.9) | | | Prevalence of Impulsivity (N):
| | Did not complete outcome assessment: N = 1 (AN group) | (P = NS) | | | AN: 13
| | Analysis sample: | Mean Time Between Baseline and FU 2, yrs (range): | | | Comparisons: 9
| | AN: 50 | AN: 8.4 (8.1–8.8) | | | (P = NS)
| | Control: 51 | Comparisons: 8.1 (7.7–8.4) | | | Personality Disorder Prevalence:
| | FU 1 = 6 yrs from AN onset | (P = NS) | | | Any Cluster A (P = NS)
| | FU 2 = 10 yrs from AN onset | Mean Time Between FU 1 and FU 2, yrs: | | | Any Cluster B (P = NS)
| | | AN: 3.5 | | | Any Cluster C (P < 0.05) AN > Comparisons, particularly for OCPD
| | | Comparisons: 3.4 | | | Any PD (P < 0.05) AN > Comparisons
| | | (P = NS) | | | Prevalence of Autism Spectrum Disorder (N):
| | | Sex: | | | AN: 9
| | | Female: 94% | | | Comparisons: 1
| | | Race/ethnicity: | | | (P < 0.02) AN > Comparisons
| | | NR | | | Clinical Severity Outcome of AN sample using M-R Scale by subgroup status (consistent comorbid dx across all three time points):
| | | | | | AN with OCPD/ASD: 7.3 (1.3)
| | | | | | AN without OCPD/ASD: 9.8 (2.1)
| | | | | | (P < 0.01) Comorbid group worse than non-comorbid group
| | | | | | Mean TAS-20 Scores for AN sample by Subgroup status (consistent comorbid dx across all three time points):
| | | | | | AN with OCPD/ASD: 54.5 (14.4)
| | | | | | AN without OCPD/ASD: 39.9 (11.0)
| | | | | | (P = 0.002) Higher alexithymia in comorbid AN group
Authors, yr: | Calculate a standardized mortality rate for eating disorders in a large population | Inclusion: | Mean Age (yrs): | Score: | Study methods | Descriptive Results
Patton, 1988 | | Eating disorder dx | AN: 22.4 | Fair | Attempted to locate by: | Mortality rate
Design: | | AN (Russell, 1970): | BN: 23.5 | Method of dx: | Contact with referring physician | Crude mortality rate (%):
Case series | | Loss of 25% of BW | Mean Wt (kg): | Russell diagnostic criteria for AN and BN applied retrospectively to case note description of presentation | Last known address | AN: 3.1
Comparison Group: | | Amenorrhea | AN: 41 | Funding | National Health Service Central Registry | BN: 3.3
No | | Fear of putting on wt | BN: 58.9 | Grant from the Wellcome Foundation | Located 95.6% | Expected mortality rate:
Location: | | BN (Russell, 1979): | Sex: | | FU conducted, 1985-86 | AN: 1.83
United Kingdom | | Uncontrollable urge to overeat (binge) | Female: 95.9% | | Sex specific death rates derived from 1981 death rates for England and Whales | BN: 0.32
Yrs followed, mean (SD): | | Self-induced vomiting or laxative abuse (Purge) | Male: 4.1% | | Analysis methods | Standardized mortality rate
AN: 7.6 (3.0) | | Feat of becoming fat | Race/ethnicity: | | Observed mortality rate (study population) | AN: 6.01 (P < 0.01) Higher than expected
BN: 5.7 (2.1) | | Exclusion: | NR | | Expected mortality rate (general population) | BN: 9.38 (P = NS)
Range: 4–15 | | NR | Mean Age of Onset (yrs): | | Standardized mortality ratio (SMR) = observed / expected | AN mortality rate (by length of FU):
| | Recruitment: | AN: 18.9 | | Stepwise linear discriminant function analysis: to examine the relationship of crude mortality to the prognostic variables | Actual mortality
| | Reviewed records of all eating disordered patients assessed in the eating disorders unit of the Academic Department of Psychiatry at Royal Free Hospital, 1971-81. | BN: 18.6 | | | Overall: 11
| | Sample size: | Mean Duration of Illness (yrs): | | | After 4 yrs: 6
| | Initial: | AN: 3.5 | | | After 8 yrs: 1
| | N = 481 | BN: 4.9 | | | Expected mortality rate
| | Reasons for loss to FU: | 2 ^ nd ^ Dx at Assessment: | | | Overall: 1.83
| | Lost to FU: N = 21 | Depression, N = 52 | | | After 4 yrs: 1.04
| | Deaths: N = 14 | AN: N = 26 | | | After 8 yrs: 0.37
| | - AN: N = 11; - Suicide: N = 6; - Low wt: N = 5; - BN: N = 3; - Car accident: N = 2; - Low wt: N = 1 | BN: N = 26 | | | Standardized mortality rate
| | Analysis sample: | | | | Overall: 6.01 (P < 0.01) Higher than expected
| | Located / Analyzed: N = 460 | | | | After 4 yrs: 5.76 (P < 0.05) Higher than expected
| | - AN: 332 (72.1%); - BN: 96 (20.9%); - Other: 32 (7.0%) | | | | After 8 yrs: 2.70 (P = NS)
| | | | | | Predictors of mortality in individuals with AN
| | | | | | wt < 35 kg at presentation:
| | | | | | Crude (%): 8.1 (N = 5)
| | | | | | Expected: 0.33
| | | | | | Standardized: 15.15 (P < 0.05) Higher than expected
| | | | | | More than one inpatient admission:
| | | | | | Crude (%): NR
| | | | | | Expected: NR
| | | | | | Standardized: NR (P < 0.01) Higher than expected
| | | | | | age < 20 yrs at presentation:
| | | | | | Crude (%): 2.8 (N = 4)
| | | | | | Expected: 0.41
| | | | | | Standardized: 9.76 (P = NS)
| | | | | | age 20–29 yrs at presentation:
| | | | | | Crude (%): 2.9 (N = 4)
| | | | | | Expected: 0.56
| | | | | | Standardized: 7.09 (P = NS)
| | | | | | age ≤ 30 yrs at presentation:
| | | | | | Crude (%): 6.0 (N = 3)
| | | | | | Expected: 0.86
| | | | | | Standardized: 3.49 (P = NS)
Authors, yr: | To identify a sensitive BMI cutoff at admission in order to predict low BMI at 1-yr FU in a sample of AN patients who had gone through an inpatient tx program. | Inclusion: | Mean Age at Admission, yrs (SD): | Score: | Study Methods | Descriptive Findings
Pinter et al., 2004 | | Met DSM IV criteria for AN; were able to obtain FU data | 21.7 (6.68) | Poor | All included participants underwent intensive, multi-dimensional inpatient tx program for AN. This first phase of tx typically lasted 5–6 mos. Following this, patients were then followed in an aftercare program that consisted of attending outpatient group meeting every two wks for an additional 6 mos. Wt assessments conducted at end of inpatient tx (i.e., approximately 6 mos) and at the termination of the outpatient FU (i.e., at 1-yr). | Changes in BMI from 6-m to 1-yr (% of sample):
Design: | | Exclusion: | Range: 12–40 | Method of dx: | Patients' BMI and clinical severity assessed using Maudsley Body Mass Index Chart. | Unchanged: 12.5%
Case series | | Co-morbid somatic problems | Mean BMI at Admission, kg/m^2 (^SD): | Not reported | Statistical Analyses | Increase: 45.2%
Comparison Group: | | Recruitment: | 14.5 (1.62) | Funding | Pearson's product moment correlations to evaluate linear associations between BMI values at intake and at 1-yr FU. | Decrease: 42.2%
No | | 252 consecutive patients admitted into inpatient Eating Disorders Unit of the U Centre Sint-Jozef in Kortenberg, Belgium for AN between 1994 and 2001. 232 patients met inclusion criteria. | Mean BMI at 6-mo FU, kg/m^2^ (SD): | NR | Mann-Whitney U tests performed to identify sig BMI cut points inclusive of the range of 12–16 kg/m^2^ to separate those with high versus low BMIs at 1-yr FU based on baseline or admission BMI. | BMI and Clinical Status Severity Category at 1-yr FU (N):
Location: | | Sample size: | 18.7 (1.22) | | | < 12 (life threatening AN): 0
Kortenberg, Belgium | | Initial Sample | Mean BMI at 1-yr FU, kg/m^2^ (SD): | | | 12–13.5 (Critical AN): 4
Yrs followed: | | 252 admitted | 18.2 (1.8) | | | 13.5–15 (Severe AN): 6
1 | | Reasons for loss to FU: | Sex: | | | 15–17.5 (AN): 62
| | Not reported | Female: 100% | | | 17.5–20 (Underwt): 131
| | Analysis Sample | Race/ethnicity: | | | 20–25 (Normal wt): 29
| | 232 had 1-yr FU data | NR | | | Correlations Between BMI at Admission and 1-yr FU:
| | | | | | r = 0.24
| | | | | | Admission BMI Cut-offs Predicting 1-yr FU BMI:
| | | | | | < / = or > 12 (P = NS)
| | | | | | < / = or > 13 (P = NS)
| | | | | | < / = or > 14 (P < 0.01)
| | | | | | < / = or > 15 (P < 0.001)
| | | | | | < / = or > 16 (P < 0.001)
Authors, yr: | To analyze the associated physical and neurodevelopmental problems in individuals with AN over 6 yrs after disease onset, and a matched comparison group. | Inclusion: | Age of AN onset (yrs): | Score: | Study Methods: | Descriptive Results
Råstam, Gillberg, and Gillberg; 1995 | | Cases: | 14.3 | Good | At time of dx, all participants and their mothers were interviewed by a psychiatrist. At FU, were screened by another psychiatrist/psychologist blind to the original group status. Both groups screened: via SCID-II for personality disorder dx, clinician-based capacity for empathy, Dewey social awareness test, neurological testing, WAIS-R, wt, and ht (self-report). All individuals examined by psychiatrist who administered first interview, using SCID-I for Axis I disorders, M-R AN outcome scales, and rating of empathic skills. At end of interview, DSM III-R dx made independently by both clinicians; empathy dx was made conjointly by both. | Axis I Dx:
Companion article: | | DSM III-R for AN | Range:13.9–14.7 | Method of dx: | Neurodevelopmental exam included growth charts of wt and ht development from age 7 through time of 1^st^ exam; wt and ht immediately before onset of AN compared to FU data. | ED at FU in AN group:
Ivarsson et al., 2000 | | Born 1970 | Mean Age at First Exam: | Structured interview using the SCID-I | AN Outcomes classifications (1) recovered/not-recovered (2) avg M-R scale scores (3) good, intermediate and poor outcome: good = nrml body wt (100 +- 15% avg body wt.), intermediate = normal or near normal wt and/or menstrual abnormalities, poor = low wt and absent or scanty menstruation. (BMI or % wt details regarding these definitions were NR). | AN: 6%
Nilsson et al., 1999 | | AN onset < 18 yrs old | G1: 16.0 (95% CI: 15.5–16.5) | Funding | Statistical Methods: | BN: 22%
Wentz et al., 2001 | | Comparison: | G2: 16.0 (95% CI: 15.5–16.5) | Swedish Medical Research Council, Swedish Social Research Council, Swen Jerring Foundation, Fulbright Commission, Wilhelm and Martina Lundgren Foundation | Chi-square tests for matched pairs were used. | EDNOS: 14%
Wentz et al., 2000 | | Matched to cases on age, sex, school | Mean Age at FU: | | | None: 59%
Design: | | Exclusion: | G1: 21 (95% CI: 20.5–21.4) | | | EAT Scores at FU, mean:
Prospective cohort | | Cases: | G2: 20.8 (95% CI: 20.3–21.3) | | | Cases: 19.2, 95% CI (13.1–25.1)
Comparison Group: | | None | Sex (both groups), N: | | | Comparisons: 5.3, 95% CI (4.2–6.4)
Yes | | Comparisons: | Females: 96 | | | Diff between groups (P < 0.001)
Location: | | None | Males: 6 | | | Comparison Axis I disorders between AN and control group at age 21 (mean of 6 yrs after onset)
Göteburg, Sweden | | Recruitment: | Race/ethnicity: | | | Affective Disorders
Yrs followed: | | Cases: From total population of Göteburg, Sweden, born in 1970 and developing AN before age 18; pooled with second population screening sample reported by school and hospital health care workers during FU. Some clinically referred and some screened through school nurses and doctors, pediatricians, and child psychiatrists | NR | | | Unipolar major depression (P = NS)
From onset to FU | | Comparisons: Same schools as AN group | | | | Any affective disorders (P = NS)
Cases: 6.7 from onset | | Sample size: | | | | Anxiety Disorders
From first exam to FU: | | Cases: 51 | | | | Agoraphobia (P = NS)
Cases: 4.9, | | Comparisons: 51 | | | | Social phobia (P = NS)
Comparisons: 4.6 | | | | | | Panic disorder (P = NS)
| | | | | | Generalized anxiety disorder (P = NS)
| | | | | | Any anxiety disorder except OCD (P = NS)
| | | | | | OCD:
| | | | | | Cases: N = 10
| | | | | | Comparisons: N = 3 (P < 0.05)
| | | | | | Psychotic Disorders
| | | | | | Schizoaffective disorder (P = NS)
| | | | | | Psychosis NOS (P = NS)
| | | | | | Schizophrenic disorder (P = NS)
| | | | | | Any psychotic disorder (P = NS)
| | | | | | Somatoform Disorders:
| | | | | | Somatization disorder (P = NS)
| | | | | | Hypochondria (P = NS)
| | | | | | Body dysmorphic disorder (P = NS)
| | | | | | Any somatization disorder (P = NS)
| | | | | | Tic Disorders:
| | | | | | Tourette's disorder (P = NS)
| | | | | | Impulse control Disorders:
| | | | | | Trichotillomania (P = NS)
| | | | | | Any tic disorder (P = NS)
| | | | | | Simple Phobias:
| | | | | | (P = NS)
| | | | | | Comparisons of any Axis I Dx in AN and control groups over time:
| | | | | | All but 1 Case, and 39% of Comparison group met criteria for at least one Axis 1 disorder in their lifetime. (P < 0.001)
Authors, yr: | To analyze overall outcome, and associated physical and mental health problems at 10 yr FU among teenage-onset AN population and matched controls. | Inclusion: | Age of AN onset: | Score: | Treatment received by Cases: | AN Outcomes classification:
Råstam, Gillberg, and Wentz 2003 | | Cases: | 14.3 yrs | Good | Lifetime tx for ED: 29 (57%) | Full recovery: free of symptoms of AN or BN for not less than 8 consecutive wks including sustained absence of wt deviation, compensatory behaviors, deviant attitudes regarding wt and shape including wt phobia. Also relaxed attitude towards eating in general for not < 6 mos.
Design: | | DSM III-R for AN | Range: 13.9–14.7 | Method of dx: | Conjoint family therapy: 19 | Modified M-R Outcome categories:
Prospective cohort | | Born 1970 | Restrictors: 13.3 yrs; 95% CI (12.1–14.6) | Structured interview using the SCID-I | Individuals with ASD and/ or OCPD: 6/8 | Good: normal body wt (100 +- 15%avg body wt.) + normal menstruation
Comparison Group: | | AN onset < 18 yrs old | Bingers/purgers: 14.6; 95% CI (14.2–15.0) | Funding | No tx: 12 | Intermediate: normal or near normal wt or normal menstrual but not both,
Yes | | Comparison: | (P < 0.05) | Swedish Medical Research Council, Göteburg Medical Society, Wilhelm and Martina Lundgrem Foundation, Soderstrom-Konigska Nursing Home Foundation, and state grants under LUA agreement. | Tx for individuals with persisiting ED: 11/14 | Poor: under wt and absent or scanty menstruation. (BMI or % wt details regarding these definitions were NR).
Location: | | Matched to cases on age, sex, school | Mean Age at First Exam: | | Tx for recovered AN: 18/37 | Descriptive Results at 10 yr FU
Göteburg, Sweden | | Exclusion: | Cases: 16.0 | | Study Methods: | ABW (kg):
Yrs followed: | | Cases: | (95% CI: 15.5–16.5) | | Each individual seen by 3 psychiatrists, 1 blind to the original dx group status. | Cases: 62.3,95% CI (58.5–66.1)
10 | | None | Comparisons: 16.0 | | Measurements: SCID-I and SCID-II for DSM IV; Y-BOCS; ASDI (Asperger Syndrome Diagnostic Interview); Modified M-R Scales; GAF scale. | Comparisons: 63.7, 95% CI (60.8–66.5)
| | Comparisons: | (95% CI: 15.5–16.5) | | Full recovery with respect to ED symtomatology; Psychiatric tx; Neuropsychiatric exam; physical exam, Self report: EAT, BDI. | (P = NS)
| | None | Mean Age at FU: | | Statistical Methods: | Mean BMI:
| | Recruitment: | Cases: 24.5 (95% CI: 24.0–25.0) | | Chi-square tests for matched pairs were used. | Cases: 22.2, 95% CI (21.0–23.4)
| | Cases: From total population of Göteburg, Sweden, born in 1970 and developing AN before age 18; pooled with second population screening sample reported by school and hospital health care workers during FU. Some clinically referred and some screened through school nurses and doctors, pediatricians, and child psychiatrists. 48 screened via personal interview, 3 via phone | Comparisons: 24.2 (95% CI: 23.7–24.7) | | | Comparisons: 22.2, 95% CI (20.5–21.8)
| | Comparisons: | Sex, N: | | | (P = NS)
| | Same schools as AN group; 51 screened in person | Females: 96 | | | ED in AN group:
| | Sample size: | Males:6 | | | AN 3 (6%)
| | Cases: 51 | Race/ethnicity: | | | BN 2 (4%)
| | Comparisons: 51 | NR | | | EDNOS 9 (18%)
| | | Full-time employment/ | | | Any ED 14 (27%)
| | | study: | | | Absence of any ED symptoms for at least 6 mos:
| | | Cases: 65%, | | | Cases: 20 (39%)
| | | Comparisons: 88% (P < 0.01) | | | Comparisons: 46 (90%)
| | | Mean duration of AN, yrs: | | | Diff between groups (P < 0.0001) Cases less likely than Comparisons
| | | Cases: 3.3, 95% CI (2.7–3.8) | | | Diff in current Axis I Psychiatric Dx:
| | | Total duration of EDs, yrs: | | | Any affective disorder, current (P = NS)
| | | Cases: 6.3 | | | Current Axis I, excluding ED (P = NS)
| | | 95% CI (5.4–7.2) | | | Panic disorder, social phobia, simple phobia, general anxiety disorder, any anxiety disorder (P = NS)
| | | | | | Current OCD: Cases: N = 8; Comparisons: N = 1; (P = 0.05)
| | | | | | Psychotic disorders (P = NS)
| | | | | | Impulse control disorders (P = NS)
| | | | | | Somatoform dx (P = NS)
| | | | | | Tic disorders (P = NS)
| | | | | | Diff in lifetime Axis I Psychiatric Dx:
| | | | | | Major Depression and Dysthymic disorders (P = NS)
| | | | | | Any affective disorder: Cases: N = 49; Comparisons: N = 12 (P < 0.0001)
| | | | | | Panic disorder, social phobia, simple phobia, general anxiety disorder, any anxiety disorder excluding OCD (P = NS)
| | | | | | OCD: Cases: 18; Comparisons: 5 (P = 0.01)
| | | | | | Any anxiety disorder, including OCD: Cases: 29, Comparisons:16
| | | | | | (P = 0.02)
| | | | | | Psychotic disorders (P = NS)
| | | | | | Impulse control disorders (P = NS)
| | | | | | Somatoform dx (P = NS)
| | | | | | Tic disorders (P = NS)
| | | | | | Any Axis I, including ED: Cases: 51, Comparisons: 26; (P = 0.0001)
| | | | | | Any Axis I, excluding ED: Cases: 51, Comparisons: 26; (P = 0.0001)
| | | | | | Diff in Axis II disorders:
| | | | | | Cluster A
| | | | | | All categories currently (P = NS)
| | | | | | All cluster A ever (P = NS)
| | | | | | Cluster B
| | | | | | All categories currently (P = NS)
| | | | | | All categories ever (P = NS)
| | | | | | Cluster C
| | | | | | Avoidant: Cases currently (P = NS)
| | | | | | Dependent currently (P = NS)
| | | | | | Obsessive-compulsive currently (P = NS)
| | | | | | Passive-aggressive currently (P = NS)
| | | | | | Any cluster C currently: Cases: 11, Comparisons: 4; (P < 0.05)
| | | | | | Any cluster C ever: Cases: 32, Comparisons: 11; (P < 0.01)
| | | | | | Autistic disorder, Asperger syndrome, Autistic-like condition, OCPD currently (P = NS)
| | | | | | OCPD ever: Cases: 28, Comparisons: 7; (P < 0.001)
| | | | | | ASD currently: Cases: 9; Comparisons:1; (P < 0.02)
| | | | | | ASD ever: Cases: 12, Comparisons: 1; (P < 0.01)
| | | | | | Any OCPD/ASD currently: Cases 14, Comparisons: 6 (P < 0.05)
| | | | | | Any OCPD/ASD ever: Cases: 32, Comparisons: 8; (P < 0.001)
| | | | | | Any OCPD/ASD at baseline, 1^st^ and 2^nd^ FU: Cases: 8, Comparisons: 0; (P < 0.02)
| | | | | | Other personality disorders
| | | | | | Self-defeating (P = NS)
| | | | | | Any SCID personality disorder (P = NS)
| | | | | | Mean age of OCD onset (P = NS)
| | | | | | Overall Outcome Measures:
| | | | | | Diff in avg M-R Scale Outcomes:
| | | | | | Cases: Good: 49%; Intermediate: 41%; Poor: 10%
| | | | | | Cases: 9.4, 95% CI (8.8–10.0), Comparisons: 11.2, 95% CI (10.8–11.5)
| | | | | | (P < 0.0001)
| | | | | | Diff in modified M-R Scale Outcomes:
| | | | | | Cases:
| | | | | | Good: 43%
| | | | | | Intermediate: 29%
| | | | | | Poor: 27%
| | | | | | Diff in dietary Restriction:
| | | | | | Cases: 47%
| | | | | | Comparisons: 16% (P < 0.01)
| | | | | | Diff in worry about wt and appearance:
| | | | | | Cases: 69%
| | | | | | Comparisons: 27% (P < 0.001)
| | | | | | Diff in normal menstruation:
| | | | | | Cases: 65%
| | | | | | Comparisons: 85% (P < 0.05)
| | | | | | AN group very poor overall outcome (M-R score < 8.5) (N):
| | | | | | Cases at 6 yr FU: 20
| | | | | | Cases at 10 yr FU: 16
| | | | | | Correlation between avg FU scores at 6 and 10 yrs: r = 0.72 (P < 0.0001)
| | | | | | Diff GAF scale, mean scores:
| | | | | | Case: 65.3, 95% CI (61.0–69.7)
| | | | | | Comparisons: 84.8, 95% CI (81.7–87.9)
| | | | | | (P < 0.0001)
| | | | | | AN group outcomes in relation to psychiatric disorders and PDs:
| | | | | | M-R Score:
| | | | | | Cases OCPD/ASD at baseline, 1st and 2nd FU: 7.3
| | | | | | All other cases: 9.8 (P < 0.01)
| | | | | | Median GAF Score:
| | | | | | Cases with Axis 1: 60
| | | | | | All other cases: 75 (P < 0.01)
| | | | | | Mean GAF Score:
| | | | | | Cases with OCD: 50
| | | | | | All other cases: 70 (P < 0.02)
| | | | | | Diff neurodevelopmental and other physical problems:
| | | | | | Fine and gross motor skills, tremor, mirror movements, handedness (P = NS)
| | | | | | Dysdiadochokinesis:
| | | | | | Cases: 11
| | | | | | Comparisons: 2 (P < 0.02)
| | | | | | GI problems:
| | | | | | Cases: 47%
| | | | | | Comparisons: 27% (P < 0.05; P < 0.055 adj)
Authors, yr: | To assess outcomes and comorbid mood and personality disorders in patients dx with AN during childhood or adolescence. | Inclusion: | Mean Age: | Score: | Study Methods: | Descriptive Results:
Saccomani et al., 1998 | | AN dx at admission based on Feighner's, DSM III, or DSM III-R criteria. Dx reclassified at FU using DSM IV | NR | Poor | Records survey of all patients admitted between 1976-1990 meeting criteria for AN by Feighner's, DSM III, DSM III-R criteria. | AN Outcome:
Design: | | Exclusion: | Mean Age of Onset, yrs, mean (range): | Method of dx: | At FU, patients sent a questionnaire designed by investigators to evaluate AN clinical features, social adjustment, familial and sexual relations, mental state, and psychiatric disorders in the previous 6 mos; and the Middlesex Hospital Questionnaire (MHQ). Information used to determine Jeammet scale (modified M-R Scale). | Good: 43 (53%)
Case series | | None | 14.5 (9 to 21) | Initial inclusion dx: Feighner's, DSM III, or DSM III-R criteria by chart review | Corraborative data gathered from semi-structured interview of family or boyfriends. | Intermediate: 27 (33%)
Comparison Group: | | Recruitment: | % Wt Loss, mean (SD): | No info provided about qualifications of reviewers or method. | Of 81 patients contacted, all completed both questionnaires, 28 had face-to-face semi-structured interview, 39 agreed only to phone interview, and 2 patients had info provided by psychotherapist. | Poor: 11 (14%)
No | | Record survey of patients admitted to Gaslini Dept of Neurology and Psychiatry between 1976-1990. | 28.3 (6.3) | Dx reclassified at FU using DSM IV. No info provided about diagnosticians or method. | Statistical Method: | Binge eating by outcome group
Location: | | Sample size: | BMI kg/m ^ 2 ^ , mean (SD): | Funding | Kruskal-Wallis analysis of variance for continuous data | Poor: 45%
Genoa, Italy | | Initial sample: | 13.9 (1.8) | None reported | Fisher tests for categorical data | Intermediate: 28%
Yrs followed: | | Identified through records: | Sex: | | Outcomes: | Good: 14%
Mean 9.6 yrs, Range 4 to 19 yrs | | N = 87 | Female, N = 72 | | Jeammet (modified M-R Outcome Scale): | (P = 0.034)
| | Reasons for loss to FU: | Males, N = 9 | | Good - 8 of 10 items score a 1 or 2 (on 4 patient. scale) | Medical emergencies by outcome group
| | 2 not found, 4 refused | Amenorrhea: | | Intermediate - 4 to 7 items score 1 or 2 (on 4 patient. scale) | Poor: 55%
| | Analysis sample: | 100% of females | | Poor - < 3 items score 1 or 2 (on 4 patient. scale) | Intermediate: 21%
| | Agreed to participate at FU: | Menses resumed: | | | Good: 4%
| | N = 81 | 87% | | | (P = 0.0003)
| | | Race/ethnicity: | | | Length/type of tx by outcome group:
| | | NR | | | Outpatient tx
| | | | | | Good: 49%
| | | | | | Intermediate: 26%
| | | | | | Poor: 0%
| | | | | | Medium-term hospitalization
| | | | | | Good: 32%
| | | | | | Intermediate: 11%
| | | | | | Poor: 36%
| | | | | | Long-term hospitalization
| | | | | | Good: 0%
| | | | | | Intermediate: 37%
| | | | | | Poor: 36%
| | | | | | Co-morbid psych dx by outcome group:
| | | | | | Personality disorders
| | | | | | Good: 0%
| | | | | | Intermediate: 41%
| | | | | | Poor: 73%
| | | | | | (P < 0.001)
| | | | | | Mood disorders
| | | | | | Good: 14%
| | | | | | Intermediate: 63%
| | | | | | Poor: 73%
| | | | | | (P = 0.002)
| | | | | | Other diff by outcome group:
| | | | | | For eating behavior, wt, menstruation, body image, occupation, social contact, familial relationships, sexual relations, insight, mental state
| | | | | | (P = 0.001). Good better than Poor
| | | | | | For social, familial and sexual relationships, insight, and mental state
| | | | | | (P = 0.001). Good better than Intermediate
| | | | | | For wt and sexual relationships (P = 0.001). Intermediate better than Poor
Authors, year: | To compare general psychopathology, eating disorder dx status, and clinical outcome in women 10 yrs after their hospital tx for AN. | Inclusion: Modified Feighner dx criteria for AN. Other details in Halmi et al., 1979 and Halmi et al., 1991. | Mean Age, Yrs (SD): | Score: | Study Methods | Descriptive Findings:
Schork et al., 1994 | | Exclusion: | NR | Poor | ED clinical status at FU: DSM III-R ED diagnostic categories, plus two versions of the Categories of General Outcome classification scheme | M-R outcome at 10-yr FU by current ED Dx, N:
Companion articles: | | See Halmi et al., 1979, for details. | Sex: | Method of diagnosis: | 1) M-R scale: | Recovered: 16 (No ED: 16; EDNOS: 0; BN: 0; AN: 0; AN+BN: 0)
Halmi, Eckert et al., 1991 | | Recruitment: | Female | Prospective assessment using Feighner criteria; retrospective DSM-III-R. | Recovered: within 15% of IBW, normal menses, no sig disturbance in eating or body image | Good: 15 (No ED: 0; EDNOS: 8; BN: 7; AN: 0; AN+BN: 0)
Design: | | Patients who completed 35-day hospital tx study for AN. | Race/ethnicity: | Funding | Good: within 15% IBW, normal menses, but with presence of binge-eating, self-induced vomiting, laxative abuse, or other clearly abnormal eating behavior | Intermediate: 21 (No ED: 0; EDNOS: 14; BN: 7; AN: 0; AN+BN: 0)
Case series | | Sample Size (N): | NR | NR | Intermediate: weight only intermittently within 15% IBW, or some menstrual disturbance, or both | Poor: 7 (No ED: 0; EDNOS: 0; BN: 0; AN: 5; AN+BN: 2)
Comparison Group: | | Completed tx: 76 | | | Poor: weight always more than 15% below IBW during the year prior to assessment | Ratnasuriya outcome at 10-yr FU by current ED Dx, N:
No | | Completed FU: 59 | | | 2) Modified Ratnasuriya et al. (1991) scheme: | Good: 24 (No ED: 16; EDNOS: 8; BN: 0; AN: 0; AN+BN: 0)
Location: | | Reasons for loss to FU: | | | Good: weight within 15% of IBW, normal menses | Intermediate: 13 (No ED: 0; EDNOS: 13; BN: 0; AN: 0; AN+BN: 0)
USA (Iowa City, IA; Minneapolis, MN; White Plains, NY | | 3 did not complete the MMPI, 9 refused to participate, 5 deceased (causes unknown). | | | Intermediate: weight only intermittently within 15% IBW, or some menstrual disturbance, or both | Poor: 22 (No ED: 0; EDNOS: 1; BN: 14; AN: 5; AN+BN: 2)
Years followed: | | | | | Poor: weight always more than 15% below IBW during the year before assessment and absent or sporadic menses, or the occurrence of either overeating or vomiting weekly or more, regardless of weight or menstrual status | Multivariate Results:
10 | | | | | Minnesota Multiphasic Personality Inventory used to assess general psychopathology at FU. | MMPI Scales by M-R Outcome:
| | | | | Statistical Approach | Recovered had sig lower score vs. poor outcome group: hypochondriasis (P = 0.004), depression (P = 0.017), psychasthenia (P = 0.005), and schizophrenia (P = 0.027).
| | | | | Chi-square tests to assess diff across groups | Recovered sig lower score vs. intermediate outcome group: psychasthenia (P = 0.04) and schizophrenia (P = 0.019).
| | | | | MANOVA to assess outcome group differences in MMPI followed by univariate ANOVAs and Tukey-Kramer pairwise post-hoc comparisons for separate clinical scales. | MMPI Scales by Ratnasuriya Outcome:
| | | | | | Good outcome group better than poor outcome: hypochondriasis (P = 0.001), depression (P < 0.001), hysteria (P = 0.001), psychopathic deviate (P = 0.007), paranoia (P = 0.012), psychasthenia (P < 0.001), and schizophrenia (P = 0.002).
| | | | | | Intermediate Outcome group better than Poor Outcome group: on depression (P = 0.036), psychopathic deviate (P = 0.049), and schizophrenia (P = 0.042).
| | | | | | MMPI Scales by ED Dx at FU:
| | | | | | No-ED group better than AN group: hypochondriasis (P = 0.008), depression (P = 0.006), psychasthenia (P = 0.001), and schizophrenia (P = 0.012).
| | | | | | No-ED group better than BN group: hysteria (P = 0.05) and psychasthenia (P = 0.01).
| | | | | | Number of Clinically Elevated MMPI Scales by Current ED Dx at FU (N):
| | | | | | No ED: none (14); 1 (2); 2 (0); ≥ 3 (0)
| | | | | | ED-NOS: none (13); 1 (4); 2 (1); ≥ 3 (4)
| | | | | | Severe ED (AN, BN, AN+BN): none (7); 1 (1); 2 (5); ≥ 3 (8)
| | | | | | Patients with no ED more likely to have no clinically elevated scales vs. “severe ED” outcome groups (AN, BN, or AN+BN) (P = 0.001).
| | | | | | Number of MMPI Scales in Clinical Range by M-R Outcome (N):
| | | | | | Recovered: none (14); 1 (2); 2 (0); ≥ 3 (0)
| | | | | | Good: none (10); 1 (0); 2 (2); ≥ 3 (3)
| | | | | | Intermediate: none (9); 1 (4); 2 (2); ≥ 3 (6)
| | | | | | Poor: none (1); 1 (1); 2 (1); ≥ 3 (4)
| | | | | | Recovered + Good Outcome groups less likely to have clinically elevated scales vs. Intermediate + Poor Outcome groups (P = 0.003).
| | | | | | Number of MMPI Scales in Clinical Range by Ratnasuriya Outcome (N):
| | | | | | Good: none (21); 1 (2); 2 (0); ≥ 3 (1)
| | | | | | Intermediate: none (6); 1 (4); 2 (0); ≥ 3 (3)
| | | | | | Poor: none (8); 1 (1); 2 (4); ≥ 3 (9)
| | | | | | Good Outcome groups more likely to have no clinically elevated scales vs. Poor Outcome groups (P < 0.001).
Authors, yr: | To examine the predictive power of binge eating behavior in predicting first-onset substance use disorder in AN patients. | Inclusion: | Mean Age at Intake: 15.1 | Score: | Intervention: | Descriptive Results
Strober et al., 1996 | | Met DSM III-R criteria for AN at intake; 12–17 yrs 11 mos at intake | Sex: | Good | Inpatient tx | SUD Incidence During 10-yr FU:
Design: | | Exclusion: | Female: 94% | Method of dx: | Study Methods | Substance abuse: N = 11
Case series | | See original study (Strober and Yager, 1984) for more specific details | Race/ethnicity: | Method of ED dx NR, Structured clinical interviews using the SADS, Kiddie-SADS, and LIFE | Semi-structured interview, information from knowledgeable informants, M-R scale completed, LIFE completed, interview every 6 mos for 5 yrs and annually for 5 yrs. | Substance dependence: N = 7
Comparison Group: | | Recruitment: | White: 93% | Funding | Statistical Methods | Mean Onset of SUD from Intake:
No | | Consecutive inpatient admissions to UCLA Neuropsychiatric Institute, Los Angeles, CA, USA, for the tx of AN between 1980 and 1985. | Family structure: | NR | Fisher's exact test for comparisons of dichotomous variables; Survival analyses to compare groups' time to onset of SUD and effects of covariates on time-to-response were assessed via stepwise Cox regression analyses. | Total sample: 199 wks (range: 48–401)
Location: | | Sample size: | 2-parent: 79% | | | Binge eaters at intake: 163 wks
USA | | Original sample: | SES: | | | Restrictors at intake: 235 wks
Yrs followed: | | N = 97 | Middle-upper class: 91% | | | Cumulative Probability and Relative Risk of SUD During 10-yr FU:
10 | | Reasons for loss to FU: | BMI at Intake (SD): | | | Binge eaters at intake: 0.50 (SE = 0.12)
| | Subjects dropped out of tx w/in 10 days of admission and refused participation in FU. | 14.1 (1.9) | | | Restrictors at intake: 0.12 (SE = 0.04)
| | Analysis sample: | | | | Diff between groups' survival distributions: RR = 5.80 (P = 0.0001)
| | N = 95 | | | | Binge eaters faster rate of developing SUD than restrictors
| | Binge-eaters at intake (N = 18) | | | | Binge eaters at intake or FU: 0.34 (SE = 0.07)
| | Restrictors at intake (N = 77) | | | | Restrictors at both intake and FU: 0.07 (SE = 0.04)
| | Binge-eaters at intake and FU: including 23 who developed binge eating during FU | | | | Diff between groups' survival distributions: RR = 5.53 (P = 0.0007)
| | (N = 41) | | | | Binge eaters faster rate of developing SUD than restrictors
| | Restrictors at both intake and FU, no binge eating (N = 54) | | | | Diff between groups (P = NS)
| | Binge eaters at FU only | | | | Binge eaters at intake: 0.50 (SE = 0.12)
| | (N = 23) | | | | Binge eaters at FU only: 0.22 (SE = 0.09)
| | | | | | Diff between groups' survival distributions: RR = 2.89 (P = 0.05) Binge eaters at intake faster rate of developing SUD than binge eaters at FU only
| | | | | | Restrictors at both intake and FU: 0.07 (SE = 0.04)
| | | | | | Binge eaters at FU only: 0.22 (SE = 0.09)
| | | | | | Diff between groups' survival distributions (P = 0.06)
| | | | | | Binge eaters at intake: 0.50 (SE = 0.12)
| | | | | | Restrictors at both intake and FU: 0.07 (SE = 0.04)
| | | | | | Diff between groups' survival distributions: RR = 9.20 (P = 0.0001) Binge eaters faster rate of developing SUD than restrictors
| | | | | | Incidence of SUD in First Degree Relatives (%):
| | | | | | Binge eaters at intake: 55.6
| | | | | | Restrictors at intake: 14.3
| | | | | | Binge eaters at intake or FU: 31.7
| | | | | | Restrictors at both intake and FU: 14.8
| | | | | | Binge eaters at FU only: 13.0
| | | | | | Binge-eating status in relation to SUD in first degree relatives:
| | | | | | Binge eaters at intake v. Restrictors at intake: OR = 7.5, 95% CI (2.4–23.2) worse in binge eaters
| | | | | | Binge eaters at intake v. Restrictors at both intake and FU: OR = 7.2, 95% CI (2.2–23.8) worse in binge eaters
| | | | | | Binge eaters at intake or FU v. Restrictors at both intake and FU: OR = 2.7, 95% CI (1.0–7.2) worse in binge eaters
| | | | | | Binge eaters at intake v. Binge eaters at FU only: OR = 8.3, 95% CI (1.8–38.4) worse in early binge-eating
| | | | | | Restrictors at both intake and FU v. Binge eaters at FU only (P = NS)
| | | | | | Multivariate Results
| | | | | | SUD Onset
| | | | | | Binge-eating at Intake (P = 0.001)
| | | | | | Family Hx of SUD (P = NS)
| | | | | | BMI at Intake (P = NS)
| | | | | | Highest-Lowest BMI (P = NS)
| | | | | | Parental Separation/Divorce (P = NS)
| | | | | | Current/Lifetime Hx of Depression or Anxiety at Intake (P = NS)
| | | | | | New Onset of Depression or Anxiety at FU (P = NS)
Authors, yr: | To assess the long-term course of recovery and relapse and predictors of outcome in AN. | Inclusion: | Age Range At Time of Intake | Score: | Study Methods | Descriptive Results
Strober, Freeman and Morrell, 1997 | | DSM III criteria for AN | 12 to 17 yrs, 11 mos | Fair | Participants had all received inpatient tx. Interviews were scheduled at 6-mo intervals from the point of discharge throughout the first 5 yrs, and annually thereafter until completion of FU. | Partial recovery: 82/95 (86.3%)
Design: | | Exclusion: | Age range at FU: | Method of dx: | Outcome definitions | Full recovery: 72/95 (75.8%)
Case series | | NR | 22 - nearly 33 yrs | Examinations conducted by two senior faculty members. | Full recovery: free of all symptoms of AN or BN for at least 8 consecutive wks. | Current dx of chronically ill (did not achieve full/partial recovery) (N = 13): BN (9/13; 9.5%); AN, restricting (3/13; 3.2%); AN, binge eating (1/13; 1.1%)
Comparison Group: | | Recruitment: | Sex: | Funding | Partial recovery: wt within 15% of avg and normal cyclical menstruation is sustained for at least 8 consecutive wks. | Median time to partial recovery: 57.4 mos
No | | All consecutive admissions to ED inpatient tx program for AN at UCLA Neuropsychiatric Institute between 1/1/80 and 12/31/85. | Female: N = 85 (89.5%) | NR | Intermediate outcome: wt within 15% of avg not maintained with consistency, and/or there is menstrual irregularity | Median time to full recovery: 79.1 mos
Location: | | Sample size: | Race/ethnicity: | | Poor: wt < 85^%^ of avg and menstruation iabsent, or nearly always so, or if patient exhibits BN. | Cumulative Probability of Recovery Through FU by interval start time, mos:
USA | | Initial sample: | White: N = 88 (92.6%) | | Post-discharge relapse: drop in body wt to < 85 of avg, occurring prior to point at which patient meets criteria for partial recovery. | 0 mos: Partial = 2%, Full = 0%
Yrs followed: | | N = 95 | BMI, mean (SD): | | Post-recovery relapse: when patient had prospectively observed exacerbation of illness following either partial recovery or full recovery. For those following full recovery, new illness further categorized as subsyndromal if patient had reappearance of psychological symptoms but remained at least 85% of avg body wt, and syndromal if wt fell below this criterion. | 12: Partial = 10%, Full = 0%
10 to 15 yrs from time of index admission | | Loss to FU: | 14.1 (1.9); 69% of avg expected body wt | | Statistical Methods | 24: Partial = 21%, Full = 1%
| | 2 patients left hospital within 10 days of admission and refused further participation. | Duration of illness, mos, mean (range): | | Chi Square, t tests, life tables, Kaplan-Meier extension of survival analysis. | 36: Partial = 33%, Full = 9%
| | Analysis sample: | 29 mos (8 – 88 mos) | | Pairwise comparisons of survival curves for particular subgroups of interest: log rank test and Breslow (Gehen-Wilcoxon) test | 48: Partial = 55%, Full: 18%
| | N = 93 | Hx of binge eating: | | Individual predictor variables: univariate and multivariate Cox proportional hazards regression models | 60: Partial = 70%, Full = 37%
| | | N = 18 (18.9%) | | Isolate sig of individual predictors: stepwise multiple logistic regression | 72: Partial = 74%, Full = 59%
| | | Restrictor at intake: | | | 84: Partial = 75%, Full = 63%
| | | N = 77 (81.1%) | | | 96: Partial = 80%, Full = 67%
| | | Hx of self-induced vomiting: | | | 108: Partial = 84%, Full = 73%
| | | 11 (61.1%) of intake binge eaters; 17 (22.1%) of intake restrictors | | | 120: Partial = 87%, Full = 73%
| | | Prior Hospitalizations: | | | 132–180 mos: Partial = 87%, Full = 77%
| | | Psych tx for AN (24.2%) | | | Diff in psychosocial adjustment by partial recovery or better or not:
| | | Med tx for wt loss complications (35.8%) | | | Good work status, yr 5:
| | | Prior psych care | | | Partial recovered: 71%
| | | (82.1%) | | | Not partial recovered: 26%
| | | | | | OR = 7.3, 95% CI (2.9 – 18.3) (P < 0.0001)
| | | | | | Good work status, yr 10:
| | | | | | Partial recovered:80%
| | | | | | Not partial recovered:25%
| | | | | | OR = 11.8, 95% CI (3.4 – 41.6) (P < 0.0001)
| | | | | | Good social relating, yr 5:
| | | | | | Partial recovered:73%
| | | | | | Not partial recovered:54%
| | | | | | OR = 2.3, 95% CI (0.9 – 5.6) (P = NS)
| | | | | | Good social relating, yr 10:
| | | | | | Partial Recovered: 85%
| | | | | | Not partial recovered:38%
| | | | | | OR = 9.3 95% CI (2.8 – 30.4) (P < 0.0002)
| | | | | | Higher life satisfaction, yr 5:
| | | | | | Partial Recovered: 41%
| | | | | | Not partial recovered:15%
| | | | | | OR = 3.8, 95% CI (1.4 – 10.6) (P < 0.012)
| | | | | | Higher life satisfaction, yr 10:
| | | | | | Partial Recovered: 68%
| | | | | | Not partial recovered: 6%
| | | | | | OR = 32.4, 95% CI (4.1 – 259.2) (P < 0.0001)
| | | | | | Diff in psychosocial adjustment by full recovery or not:
| | | | | | Good work status, yr 5:
| | | | | | Recovered: 87%
| | | | | | Not recovered:67%
| | | | | | OR = 3.2, 95% CI (1.1 – 9.2) (P = 0.029)
| | | | | | Good work status, yr 10:
| | | | | | Recovered:96%
| | | | | | Not recovered: 62%
| | | | | | OR = 13.8, 95% CI (3.4 – 55.8) (P < 0.0001)
| | | | | | Good social relating, yr 5:
| | | | | | Recovered: 91%
| | | | | | Not recovered: 65%
| | | | | | OR = 5.6, 95% CI (1.7 – 18.2) (P = 0.003)
| | | | | | Good social relating, yr 10:
| | | | | | Recovered: 90%
| | | | | | Not recovered: 73%
| | | | | | OR = 3.3, 95% CI (1.0 – 10.5) (P = 0.053)
| | | | | | Higher life satisfaction, yr 5:
| | | | | | Recovered: 89%
| | | | | | Not recovered: 69%
| | | | | | OR = 11.9, 95% CI (4.0 – 35.3) (P < 0.0001)
| | | | | | Higher life satisfaction, yr 10:
| | | | | | Recovered: 87%
| | | | | | Not recovered: 54%
| | | | | | OR = 5.7, 95% CI (2.0 – 16.2) (P = 0.002)
| | | | | | Onset of binge eating during FU among those who were restrictors at baseline. N = 23/77 (29%)
| | | | | | Time to onset of binge eating: median (range): 24 mos (3 – 59 mos); 95% CI (16.2 – 31.8).
| | | | | | Binge eating commenced when patient within 85% of avg body expected wt: 19/23 (82.6%)
| | | | | | Fulfilled BN criteria: 16/23 (65.2%)
| | | | | | Post discharge relapse: N = 28 (29.5%)
| | | | | | Survival time, mos (mean):
| | | | | | Entire sample: 129.3, 95% CI (114.4 – 144.2)
| | | | | | In patients who relapsed: 15.0, 95% CI (10.2 – 19.9); median: 11.0, 95% CI (5.8 – 16.2)
| | | | | | Mean time to post-discharge relapse, mos:
| | | | | | Chronically ill group: 10.8, 95% CI (4.9 – 16.6); median: 7.0, 95% CI (5.6 – 8.4)
| | | | | | Patients who eventually recovered: 19.9, 95% CI (12.3 – 27.5); median: 13.0, 95% CI (4.2 – 21.8)
| | | | | | Post-Recovery Relapse:
| | | | | | Following partial recovery: N = 8 (9.8%) by 13 mos from time of partial recovery
| | | | | | Syndromal relapses following full recovery: N = 0
| | | | | | Subsyndromal relapses following full recovery: N = 5 (7.1%) by 19 mos
| | | | | | Multivariate Results
| | | | | | Predictors of Chronic Outcome (Intermediate or Poor):
| | | | | | Extreme, compulsive drive to exercise: OR = 4.3, 95% CI (1.2 – 15.3)
| | | | | | (P = 0.023)
| | | | | | Hx of poor social relating preceding onset of illness: OR = 3.5,
| | | | | | 95% CI (1.2 – 12.8) (P = 0.044)
| | | | | | Early age of onset (P = NS)
| | | | | | Predictors of longer time to full recovery
| | | | | | Hostile attitudes toward family: HR = 0.67, 95% CI (0.5 – 0.9) (P = 0.046)
| | | | | | Extreme compulsivity in daily routines: HR = 0.59, 95% CI (0.4 = 0.9)
| | | | | | (P = 0.035)
| | | | | | Early age of onset (P = NS)
| | | | | | Predictors of binge eating during FU among those who were restrictors at baseline:
| | | | | | Hostile attitudes toward family: OR = 6.7, 95% CI (2.2 – 20.2)
| | | | | | (P = 0.0007)
| | | | | | Lack of parential-expressed empathy/affection toward patient: OR = 3.1, 95% CI (1.1 – 8.6) (P = 0.028)
| | | | | | Predictors of earlier time to relapse (adj for duration of hospitalization):
| | | | | | Final outcome status (chronic versus partial or full recovery): HR = 2.5, 95% CI (1.1 – 5.5) (P = 0.027)
| | | | | | Compulsive drive to exercise at time of discharge: HR = 2.2,
| | | | | | 95% CI (1.1 – 4.9) (P = NR)
Authors, yr: | To ascertain the intermediate to long-term outcomes for women who had been referred for tx for AN an avg of 12 yrs earlier - using clear diagnostic defs and a structured method. To compare outcomes to a community sample. | Inclusion: | Mean Age (yrs) | Score: | Study Methods | Descriptive Findings
Sullivan, Bulik et al., 1998 | | Cases: Newly dx via DSM III-R criteria for definite or “probable” AN, all determined to meet lifetime DSM III-R criteria for AN; age 23–45 | At interview: | Good | Cases: Hospital record of AN patients reviewed by 2 trained abstractors | Diff in percentage of groups with dx at 12 yr FU:
Design: | | Comparisons: Age matched to AN cases; age 23–45 | Cases: 32.4 (7.8) | Method of dx: | ED attitudes measured via EDI and TFEQ | Lifetime Mood Disorders
Case Series | | Exclusion: | Comparison: 35.5 (6.2) | Criteria for DSM III or DSM IIIR determined through review of hospital records. | Psychiatric disorders defined according to DSM III-R criteria | Major depression: Cases: 51.4%; Comparisons: 35.7% (P ≤ 0.05)
Comparison Group: | | Cases: None | (P < 0.01) | Funding | Current assessment of social and occupational functioning using GAFS | Bipolar I disorder (P = NS)
Yes | | Comparisons: subthreshold AN symptoms | Cases: | Cantebury Medical Research Foundation | Statistical Methods | Bipolar II disorder (P = NS)
Location: | | Recruitment: | AN onset: 16.9 yrs (4.1) | New Zealand Health Research Council | Chi-square, ANOVA, ANCOVA | Any mood disorder: Cases: 60.0%; Comparisons: 41.8% (P ≤ 0.05)
Christchurch, New Zealand | | Cases: Newly dx via DSM III-R criteria during inpatient, outpatient or assessment from 1981-1984 among those who received ED services at Princess Margaret Hospital, Christchurch, New Zealand, for definite or “probable” AN | Age at first tx: 20.9 (8.0) | | Outcome: diff between AN and Comparison groups. | Lifetime Drug Use Disorders
Yrs followed: | | Comparisons: randomly selected names obtained from electoral record | Interval between onset and interview (yrs): | | All analyses adjust for age. | Alcohol dependence: Cases: 27.1%; Comparisons: 10.2% (P ≤ 0.05)
12 | | Both: letter to invite participation; FU phone call; personal interview | 15.4 (7.0) | | | Cannabis dependence (P = NS)
| | Sample size: | Sex: | | | Other drug dependence (P = NS)
| | Initial Sample | Female: 100% | | | Any drug dependence: Cases: 30.0%; Comparisons: 12.2% (P ≤ 0.05)
| | Records reviewed: 239 | Race/ethnicity: | | | Lifetime Anxiety Disorders
| | Potential AN: 89 | European | | | OCD: Cases: 15.9%; Comparisons: 2.0% (P ≤ 0.01)
| | Potential comparisons: 111 | Cases: 98.6% | | | Panic Disorder (P < 0.05) Cases worse
| | Reasons for loss to FU: | Comparison: 96.0% | | | Social Phobia (P = NS)
| | Death: 1 due to suicide while being treated for AN, 3 could not be located, 8 did not give consent, and 7 did not meet criteria for AN | (P = NS) | | | Separation Anxiety Disorder: Cases: 17.1%; Comparisons: 2.0% (P ≤ 0.01)
| | Analysis sample: | Never married: | | | Overanxious Disorder: Cases: 37.1%; Comparisons: 3.1% (P ≤ 0.001
| | Cases = 70 | Cases: 45.7% | | | Any Anxiety Disorder: Cases: 60%; Comparisons: 32.7% (P ≤ 0.001)
| | Comparison = 98 | Comparison: 16.3% | | | Multivariate Results
| | | (P < 0.01) | | | BMI at interview (kg/m2), Mean (SD)
| | | Managerial or professional occ: | | | Cases: 20.1 (2.1); Comparison: 25.6 (6.4)
| | | Cases: 21.4% | | | Diff between groups at endpoint controlling for age (P ≤ 0.001)
| | | Comparison: 25.5% | | | Diff between groups at endpoint controlling for age and current AN
| | | Morbidity: | | | (P ≤ 0.001)
| | | Lifetime AN | | | Ideal BMI, Mean (SD)
| | | Cases: 100%: | | | Cases: 19.6 (2.0); Comparison: 22.6 (2.6)
| | | Comparison: 0% | | | Diff between groups at endpoint controlling for age (P ≤ 0.001)
| | | Current full syndrome AN | | | Diff between groups at endpoint controlling for age and current AN
| | | Cases: 10% | | | (P ≤ 0.001)
| | | Comparison: 0% | | | EDI Subscale Scores:
| | | Current subtrhreshold AN: | | | Drive for Thinness, Mean (SD)
| | | Cases: 5.7% | | | Cases: 6.2 (6.4); Comparison: 3.1 (4.2)
| | | Comparisons: 0% | | | Diff between groups at endpoint controlling for age (P ≤ 0.01)
| | | Lifetime BN | | | Diff between groups at endpoint controlling for age and current AN
| | | Cases: 54.3% | | | (P ≤ 0.05)
| | | Comparison: 2% | | | Bulimia, Mean (SD)
| | | Current BN | | | Cases: 1.5 (2.7); Comparison: 1.0 (1.6)
| | | Cases: 11.4% | | | Diff between groups at endpoint controlling for age (P = NS)
| | | Comparison: 0% | | | Diff between groups at endpoint controlling for age and current AN
| | | | | | (P = NS)
| | | | | | Body Dissatisfaction, Mean (SD)
| | | | | | Cases: 10.3 (8.9); Comparison: 11.5 (9.3)
| | | | | | Diff between groups at endpoint controlling for age (P = NS)
| | | | | | Diff between groups at endpoint controlling for age and current AN (P = NS)
| | | | | | Perfectionism, Mean (SD)
| | | | | | Cases: 6.7 (4.7); Comparison: 3.4 (3.3)
| | | | | | Diff between groups at endpoint controlling for age (P ≤ 0.001)
| | | | | | Diff between groups at endpoint controlling for age and current AN
| | | | | | (P ≤ 0.001)
| | | | | | Three Factor Eating Questionnaire Scale Score:
| | | | | | Cognitive Restraint, Mean (SD)
| | | | | | Cases: 11.7 (5.7); Comparison: 5.5 (4.8)
| | | | | | Diff between groups at endpoint controlling for age (P ≤ 0.001)
| | | | | | Diff between groups at endpoint controlling for age and current AN
| | | | | | (P ≤ 0.001)
| | | | | | Disinhibition, Mean (SD)
| | | | | | Cases: 5.7 (4.1); Comparison: 5.9 (4.0)
| | | | | | Diff between groups at endpoint controlling for age (P = NS)
| | | | | | Diff between groups at endpoint controlling for age and current AN
| | | | | | (P = NS)
| | | | | | Hunger, Mean (SD)
| | | | | | Cases: 3.8 (2.4); Comparison: 4.8 (3.0)
| | | | | | Diff between groups at endpoint controlling for age (P ≤ 0.01)
| | | | | | Diff between groups at endpoint controlling for age and current AN
| | | | | | (P ≤ 0.05)
| | | | | | Global Assessment of Functioning Score
| | | | | | Diff between groups adjusting for case/control status, age, current ED, mood, anxiety or dependence disorder (P = 0.002)
| | | | | | Worse in AN group
Authors, yr: | To investigate: the intermediate-term outcomes of AN patients who had inpatient tx at least 4 yrs prior, and prognostic factors associated with later FU outcomes. | Inclusion: | Mean Age (SD): | Score: | Study Methods: | Descriptive Results:
Tanaka et al., 2001 | | Women | 22.7 (6.0) yrs | Fair | Retrospectively identified 61 patients with DSM IV crit. for AN who had inpatient tx at least 4 yrs prior. Contacted by telephone for face-to-face or telephone semi-structured interview and assessment. Those not participating in interview were given only assessments packets. Data confirmed by interviewing spouse or parent. Information on deceased patients provided by parent. | FU menstruation status:
Design: | | Retrospectively fit DSM IV for AN, inpatient tx min. of 4 yrs prior to study. | Range: 13.7–37.4 yrs | Method of dx: | Japanese version of EDI, EAT administered | Regular menses = 63.0%
Case series | | Exclusion: | Sex: | Retrospective using DSM IV | Statistical Method: | Amenorrhea = 22.2%
Comparison Group: | | BN | Female 100% | Funding | One way ANOVA | M-R Outcomes:
No | | Recruitment: | Age onset (SD): | NR | Chi Square | Good: 31 (51%)
Location: | | Completing inpatient tx at Osaka City University Hospital between January 1982 and December 1999, a min. of 4 yrs prior to study were contacted by telephone. Received face-to-face or telephone semi-structured interviews or just FU questionnaires if not available for interviews. Information re: deceased patients obtained from patient's parents. | 18.8 (4.3) yrs | | Kruskal-Wallis | Intermediate: 8 (13%)
Osaka, Japan | | Sample size: | Duration illness (SD): | | Outcomes | Poor: 15 (25%)
Yrs followed: | | Initial sample: | 4.1 (4.3) yrs | | M-R Outcome Assessment Schedule for prior 6 mos: Avg composite outcome from ratings on 12 patient scale of avg of 5 subscales (eating difficulties, menstrual state, mental state, psychosexual state, socioeconomic state). | Deceased: 7 (11%)
8.3 (SD 3.8) | | Patients treated (N = 185) | #Admissions (SD): | | General outcome based on wt and menstrual function for prior 6 mos: | Predictors of general outcome categories:
Range 4.0–17.7 | | Met DSM IV for AN and 4 yrs had passed (N = 69) | 1.1 (1.5) | | Good: Wt within 15% ABW and regular menses | Good vs Poor:
| | Reasons for loss to FU: | Education (SD): | | Intermediate: Wt within 15% ABW, but not sustained and/or menstrual disturbances. | Younger at referral (P = 0.01)
| | Deceased (N = 7) | 12.3 (2.8) yrs | | Poor: Wt less than within 15% ABW and menses absent or near absent OR bingeing and or purging wkly | Younger at admission (P = 0.01)
| | Emaciation (N = 3) | BMI (SD) (kg/m ^ 2 ^ ): | | | Higher BMI at FU (P < 0.001)
| | Suicide (N = 2) | 14.0 (2.1) | | | Higher min BMI (P = 0.005)
| | Murdered (N = 1) | Premorbid BMI (SD) (kg/m ^ 2 ^ ): | | | Good vs. Intermediate:
| | Burn to death (N = 1) | 20.5 (2.8) | | | Higher BMI at FU (P < 0.001)
| | Refused (N = 1) | Max BMI (SD) (kg/m ^ 2 ^ ): | | | Good vs. Deceased:
| | Analysis sample: | 21.9 (4.0) | | | Fewer number of admissions (P = 0.001)
| | N = 61 (not including 7 deceased patients) | Min BMI (SD) (kg/m ^ 2 ^ ): | | | Intermediate vs. Deceased:
| | | 12.9 (2.4) | | | Fewer number of admissions (P = 0.001)
| | | AN-R: 44.3% | | | Poor vs. Deceased:
| | | AN-BP: 55.7% | | | Fewer number of admissions (P = 0.001)
| | | Suicide attempts: | | | Predictors at FU of M-R outcome categories:
| | | 39.30% | | | Good vs. Poor:
| | | Alcohol abuse: | | | Higher food intake (P < 0.001)
| | | 8.20% | | | Higher body wt (P < 0.001)
| | | At FU: | | | Better menstrual state (P < 0.001)
| | | Duration of illness after onset (SD): | | | Better mental state (P < 0.001)
| | | 12.4 (5.3) yrs | | | Better attitude towards sexual matters (P = 0.002)
| | | BMI (SD) (kg/m ^ 2 ^ ): | | | Greater overt sexual behavior (P < 0.001)
| | | 18.2 (3.4) | | | Better relationship with family (P < 0.001)
| | | BMI | | | Greater emancipation from family (P < 0.001)
| | | < 17.5: 31% | | | Greater social contacts outside family (P = 0.03)
| | | | | | Greater social activities outside family (P < 0.001)
| | | | | | Good vs. Intermediate:
| | | | | | Higher food intake (P < 0.001)
| | | | | | Higher body wt (P < 0.001)
| | | | | | Better menstrual state (P < 0.001)
| | | | | | Greater emancipation from family (P < 0.001)
Authors, yr: | Report the long-term outcome of AN using an intensive and comprehensive evaluation at FU in a large enough sample for statistical validity after an adequate observation period. Comparing outcome across three hospital points of contact. | Inclusion: | Mean Age at baseline (yrs): | Score: | Study Methods | Subjects deceased: 9
Tolstrup et al., 1985 | | Dx of AN by the following criteria: | Total: 19 | Poor | FU record review conducted 1981-82 | Cause of death: suicide 6; malnutrition 2; unclear: 1
Design: | | Wt loss via reduced food intake, vomiting or excessive activity; Amenorrhea (if reproductive age); Distorted body image; clinical picture not explained by other somatic or psychiatric illness | Child Psychiatry: 15.2 | Method of dx: | Surviving subjects contacted and invited to participate in semi-structured interview lasting approx 120 min (87 were audiotaped; 12 were videotaped) | Mean age at death: 27.1 yr
Case series through record review and FU | | Exclusion: | Psychiatry: 24.2 | Review of records by authors to meet the diagnostic inclusion criteria | The interview included: | Department of primary contact for the deceased: Child Psychiatry: 1; Psychiatry: 5; Internal Medicine: 3
Comparison Group: | | Inpatient < 1 wk or < 2 outpatient visits; Other somatic dx (e.g., ulcer, psychosis) | Internal Med: 21.7 | Funding | - Determination of socioeconomic status (SES); - Global clinical evaluation | Global Clinical Evaluation:
No | | Recruitment: | Sex: | the Danish Medical Research Council, the Gangsted-Rasmussen Fonde, the Enketru C. Hermansens Mindelegat, the Petra Slettens Fond | General somatic outcome: | Well-functioning: 49 (43%)
Location: | | Review of all hospital records with a dx of AN from three departments at Rigshospital, University of Copenhagen, Child Psychiatry, Psychiatry, and Internal Medicine, 1960-1976. | Female: 140 | | Good: wt ≥ 86% ABW, normal menstruation (if female) | Moderately impaired: 44 (39%)
Copenhagen, Denmark | | Sample size: | Male: 11 | | Intermediate: Wt 71 – 85% ABW | Poorly functioning: 21 (18%)
Yrs followed: | | Initial sample: | Race/ethnicity: | | Poor: wt ≤70 % ABW; Psychiatric dx | General somatic outcome, N (%)
Mean = 12.5 | | Records reviewed: 192 | NR | | Subjects who were also parents were invited to participate in supplementary interview on parental functioning | Good: 60 (40)
Range (4–22) | | Records selected: 151 | Mean % Underwt (at baseline): | | For those subjects who could not be interviewed in person, interview was mailed as a questionnaire when possible. | Intermediate: 44 (29)
| | Child Psychiatry: 64 | Total: 32 | | In some cases, hospital records or government records were only information available | Poor: 29 (19)
| | Psychiatry: 51 | Child Psychiatry: 29 | | Outcomes: | Dead: 9 (5)
| | Internal Medicine: 36 | Psychiatry: 34 | | Global clinical evaluation: Interviewer's evaluation | Diff between departments (P = NS)
| | Reasons for loss to FU: | Internal Med: 34 | | General somatic outcome, modification of M-R criteria: | Diff between departments over time (P = NS)
| | Deaths: N = 9 | Mean duration of Illness at baseline (yrs): | | Good: wt 86–114% of ABW, menstruation normal | Psychiatric dx, N (%)
| | Analysis sample: | Total: 2.4 | | Intermediate: wt 71%-85% of ABW, and menstruation mostly absent or sporadic | No mental disorder: 61 (47)
| | N = 142 surviving at FU | Child Psychiatry: 1.4 | | Poor: wt 70% of ABW or less, menstruation mostly absent or sporadic | AN: 37 (25) (includes 8 with BN variants)
| | Interviewed: 114 | Psychiatry: 3.2 | | | Neurosis: 15 (11)
| | Questionnaire: 19 | Internal Med: 2.1 | | | Psychotic depression: 9 (6)
| | Hospital records: 6 | Mean Duration of Treatment (mos): | | | Schizophrenia: 3 (2)
| | Central Registry only: 3 | Total: 12 | | | Borderline psychosis: 4 (3)
| | | Child Psychiatry: 17 | | | Character disorder: 2 (1)
| | | Psychiatry: 13 | | | Diff between departments (P = NS)
| | | Internal Med: 2.5 | | | Diff between departments over time (P = NS)
| | | Previous hospitalization (before primary contact):
| | | Total: 64%
| | | Child Psychiatry: 69%
| | | Psychiatry: 65%
| | | Internal Med: 56%
| | | Mean age at FU, yrs (range):
| | | 31 (16–63)
| | | Mean wt at FU:
| | | 84% of reference
Authors, yr: | Compare the rate of psychiatric disorders in an AN group with a community matched sample, 10 yrs after reported AN onset Examine whether long term outcome is worse in AN group and related to specific personality and/or psychiatric disorders. | Inclusion: | Mean Age (yrs): | Score: | Study Methods | Descriptive Results
Wentz et al., 2001 | | Cases: | Cases: 24.5 | Good | Assessment evaluation by a psychiatrist for Axis 1 dx; by another blinded psychiatrist for Axis 2 and ASD dx via SCID-1 and 2 structured interview (3 by telephone). Eating behavior evaluated using EAT. Outcomes based on M-R Scales, GAF | Current body wt
Companion article: | | DSM III-R for AN | 95% CI (24.0–25.0) | Method of dx: | Statistical Methods | AN: 62.3 kg, 95% CI (58.5–66.1)
Gillberg, Råstam and Gillberg, 1995 | | Born 1970 | Comparisons: 24.2 | AN evaluation by school nurse and psychiatrist by structured interview using SCID; personality disorder and/or autism via blind evaluation of case hx by psychiatrist | Chi-square test for matched and unmatched pairs for psych dx | Comparisons: 63.7 kg, 95% CI (60.8 – 66.5)
Ivarsson et al., 2000 | | AN onset < 18 yrs old | 95% CI (23.7–24.7) | Funding | Two-sample t-test for BMI, anthropometric data | Diff between groups (P = NS)
Nilsson et al., 1999 | | Comparison: | Age at onset: | Swedish Medical Research Council, Göteborg Medical Society, Wilhelm and Martina Lundgren Foundation, Göteborg Freemasons, Söderström-Königska Nursing Home Foundation, and grants from the state under the LUA agreement | McNemar test for for MR subscales | Current BMI
Wentz et al., 2000 | | Matched to cases on age, sex, school | 14.3 | | Wilcoxon (Mann-Whitney) rank sum test for median GAF scores | AN: 22.2 kg/m2, 95% CI (21.0–23.4)
Companion article: | | Exclusion: | Range: 13.9–14.7 | | Spearman rank order correlation coefficient for correlations between the M-R and GAF scores | Comparisons:22.2 kg/m2 95% CI (21.2–23.2)
Wentz et al., 2001 | | Cases: | Sex: | | Outcome Definitions | Diff between groups (P = NS)
Design: | | None | Cases: | | Full recovery from ED: no disturbed eating attitude or behavior in respect to food and shape for at least 6 mos before assessment | Free from ED Symptoms/Full Recovery from ED:
Prospective cohort | | Comparisons: | Female: 48 | | | AN: 39%
Comparison Group: Yes | | None | Male: 3 | | | Comparisons: 90%
Location: | | Recruitment: | Comparison: | | | Diff between groups (P < 0.001)
Göteberg, Sweden | | Cases: From total population of Göteburg, Sweden, born in 1970 and developing AN before age 18; pooled with second population screening sample reported by school and hospital health care workers during FU. Some clinically referred and some screened through school nurses and doctors, pediatricians, and child psychiatrists | Female: 48 | | | Diff between groups in current psychiatric disorders
Yrs followed: | | Comparisons: | Male: 3 | | | Major depression unipolar (P = NS)
10 (1985-1996) | | Same schools as AN group | Race/ethnicity: | | | Major depression bipolar I (P = NS)
| | Sample size: | NR | | | Major depression bipolar II (P = NS)
| | Cases: 51 | Full-time employment | | | Dysthymic disorder (P = NS)
| | Comparisons: 51 | Cases: 65% | | | Any effective disorder (P = NS)
| | | Comparison: 88% | | | Panic disorder (P = NS)
| | | (P < 0.01) | | | Social phobia (P = NS)
| | | Cases with at least 8 sessions of some form of tx: | | | Simple phobia (P = NS)
| | | N = 29 | | | OCD, AN: 8; Comparisons: 1 (P < 0.05)
| | | AN duration: | | | General anxiety disorder (P = NS)
| | | Cases: 3.3yrs; | | | Any anxiety disorder (P = NS)
| | | 95% CI (2.7–3.8) | | | Psychotic disorder (P = NS)
| | | ED duration Cases: | | | Substance abuse (P = NS)
| | | 6.3yrs; | | | Any axis I disorder (inc ED) AN: 27; Comparisons: 14 (P < 0.05)
| | | 95% CI (5.4–7.2) | | | Any axis I disorder (exc ED) (P = NS)
| | | BN symptoms: | | | Diff between groups in lifetime psychiatric disorders
| | | Cases: 75% | | | Major depression unipolar (P = NS)
| | | | | | Major depression bipolar I (P = NS)
| | | | | | Major depression bipolar II (P = NS)
| | | | | | Dysthymic disorder (P = NS)
| | | | | | Any effective disorder: AN: 49; Comparisons: 12 (P < 0.0001)
| | | | | | Panic disorder (P = NS)
| | | | | | Social phobia (P = NS)
| | | | | | Simple phobia (P = NS)
| | | | | | OCD: AN: 18; Comparisons: 5 (P < 0.01)
| | | | | | General anxiety disorder (P = NS)
| | | | | | Any anxiety disorder: AN: 29; Comparisons: 16 (P < 0.02)
| | | | | | Psychotic disorder (P = NS)
| | | | | | Substance abuse (P = NS)
| | | | | | Any axis I disorder (inc ED) AN: 51; Comparisons: 26 (P < 0.0001)
| | | | | | Any axis I disorder (exc ED): AN: 51; Comparisons: 26 (P < 0.0001)
| | | | | | Current Eating Disorders
| | | | | | AN: AN 6%; Comparisons: 0%
| | | | | | BN: AN 4%; Comparisons: 0%
| | | | | | EDNOS: AN:18%; Comparisons: 0%
| | | | | | Avg M-R Scale Score
| | | | | | AN: 9.4, 95% CI (8.8–10.0)
| | | | | | Comparisons: 11.2, 95% CI (10.8–11.5)
| | | | | | Diff between groups (P < 0.0001)
| | | | | | Dietary restriction
| | | | | | AN: 47%; Comparison: 16%
| | | | | | Diff between groups (P < 0.01)
| | | | | | Worry about body wt and appearance
| | | | | | AN: 69%; Comparisons: 27%
| | | | | | Diff between groups (P < 0.001)
| | | | | | Normal menstruation
| | | | | | AN: 65%; Comparisons: 85%
| | | | | | Diff between groups (P < 0.05)
| | | | | | Mean GAF Score
| | | | | | AN: 65.3, 95% CI (61.0–69.7)
| | | | | | Comparisons: 84.8, 95% CI (81.7–87.9)
| | | | | | Diff between groups (P < 0.0001)
Authors, yr: | To examine prospectively the long-term medical complications in a community- based study of AN | Inclusion: | Mean age at first examination: | Score: | Study Methods: | Descriptive Results:
Wentz et al., 2000 | | Cases: | Cases: 16.1, | Good | The two groups were examined by a psychiatrist blind to diagnostic group status, who performed all neurodevelopmental and neurological examinations. Physical examinations were also conducted on all participants, and gross motor skills, tremor, and diadochokinesis (DDK) were measured using a battery of tests. | Mean (SD) wt, height, and BMI of AN and Comparisons groups at 16, 21, and 24 yrs (10 yr FU):
Companion article: | | DSM III-R for AN | 95% CI (15.7–16.5) | Method of dx: | Poor outcome was defined by M-R classification, based on low wt and absent or scanty menstruation. Ratnasuriya et al. (1991) Modified outcome criteria was used, including persisting eating disorder in the poor outcome definition. | Wt, kg:
Ivarsson et al., 2000 | | Born 1970 | Comparisons: 16.0, 95% CI (15.5–16.6) | Independent clinician, used SCID at FU | Statistical Methods: | Cases:
Nilsson et al., 1999 | | AN onset < 18 yrs old | Mean Age at FU | Funding | Neurodevelopmental tests and the frequencies of physical disorders were analysed with the x^2^ tests. | 16 yrs: 49.4 (8.8) diff between cases and comparisons (P < 0.01)
Råstam, Gillberg and Gillberg, 1995 | | Comparison: | Case: 24.5, 95% CI (24.0 -25.0) | Medical Research | | 21 yrs: 58.9 (11.8)
Wentz et al., 2001 | | Matched to cases on age, sex, school | Comparisons: 24.2, 95% CI (23.7–24.7) | Council grant, | | 24yrs: 62.3 (12.7)
Design: | | Exclusion: | Sex: | Wilhelm and Martina Lundgren Foundation, Göteborg Medical | | Comparisons:
Prospective cohort | | Cases: | Cases: | Society, Göteborg Freemasons, Söderström-Königska | | 16 yrs: 56.2 (6.6)
Comparison Group: Yes | | None | Females: 48 | Nursing Home Foundation, and grants from the State | | 21 yrs: 60.4 (7.9)
Location: | | Comparisons: | Males: 3 | | | 24yrs: 63.7 (10.0)
Göteberg, Sweden | | None | Race/ethnicity: | | | BMI, kg/m2:
Yrs followed: | | Recruitment: | NR | | | Cases:
10 (1985-1996) | | Cases: From total population of Göteburg, Sweden, born in 1970 and developing AN before age 18; pooled with second population screening sample reported by school and hospital health care workers during FU. Some clinically referred and some screened through school nurses and doctors, pediatricians, and child psychiatrists | | | | 16 yrs: 18.3 (2.9)b
| | Comparisons: | | | | 21 yrs: 21.2 (3.5)
| | Same schools as AN group | | | | 24yrs: 22.2 (4.1)
| | Sample size: | | | | Comparisons:
| | Cases: 51 | | | | 16 yrs: 20.2 (1.9)
| | Comparisons: 51 | | | | 21 yrs: 21.2 (2.3)
| | | | | | 24yrs: 22.2 (3.4)
| | | | | | Diff between groups in psychiatric disorders at FU
| | | | | | Overall
| | | | | | Cases: 53%
| | | | | | Comparisons 27% (P<= 0.05)
| | | | | | Anxiety disorders
| | | | | | Cases: 35%
| | | | | | Comparisons 22% (P = NS)
| | | | | | OCD:
| | | | | | Cases: 16%
| | | | | | Comparisons 2% (P < 0.05)
| | | | | | Depressive disorder, lifetime dx
| | | | | | Cases: 96%
| | | | | | Comparisons: 24% (P < 0.0001)
| | | | | | Current depressive disorder:
| | | | | | Cases: 10%
| | | | | | Comparisons 4% (P = NS)
| | | | | | Diff between groups in physical complaints/disorders:
| | | | | | Gastrointestinal problems
| | | | | | Cases: 47%
| | | | | | Comparisons: 27% (N = 14) (P = 0.05)
| | | | | | Hirsuitism: more prevalent in cases (P = 0.05)
| | | | | | Diff between groups in neurodevelopmental findings:
| | | | | | Fine and gross motor skills, coordination, tremor, mirror movements, or handedness (P = NS)
| | | | | | Dysdiadochokinesis
| | | | | | Cases: N = 11
| | | | | | Comparisons: N = 2 (P < 0.01)

Evidence Table 16. Bulimia nervosa outcomes

Study Description | Research Objective | Eligibility Criteria, Recruitment and Sample Size | Demographic and Other Characteristics | Quality | Study Methods and Analytic Strategy | Main Outcomes and Results
Authors, yr: | To identify predictors of outcome and to assess effects of available txs for AN or BN | Inclusion: | Mean Age (SD): | Score: | Study Methods | Descriptive Results
Ben-Tovim et al., 2001 | | 15 yrs old and older; living in Adelaide, South Australia; either making first contact with secondary or tertiary services for tx of ED or were recontacting such services after a tx break of at least 6 mos. | AN: 22.5 (6.9) | Fair | Evaluation in person or by telephone annually. | AN:
Design: | | Exclusion: | BN: 23.8 (6.4) | Method of dx: | Statistical Methods | Dx at 5 yrs:
Case series | | None | Sex: | Dx made by treating clinician and confirmed by Flinders Symptom Score (FSS) interview. Dx was according to DSM III-R | Dependent variable: Total scores from M-R-H scales at 5 yrs | AN: 20 (21%)
Comparison Group: | | Recruitment: | Female: 100% | Funding: | Multiple Regression | BN: 5 (5%)
No | | Agreement to participate was obtained from all identifiable specialist service providers in Adelaide, apart from one psychiatrist in individual practice. | Race/ethnicity: | Australian National Health and Medical Research Council, Flinders 2000, and the Centre for Applied Research in Mental Health | M-R-H Subscales: | EDNOS: 9 (9%)
Location: | | Sample Size: | NR | | Subscale A: Dietary and eating patterns, body concern, and body wt | No ED: 56 (59%)
Adelaide, South Australia | | Fulfilled criteria: N = 235 | Wt, kg, Mean (SD): | | Subscale B: Menstrual pattern | Unknown: 2 (2%)
Yrs followed: 5 | | Agreed to participate: N = 220 | AN: 44.8 (6.5) | | Subscale C: Mental State | Died: 3 (3%)
| | Baseline sample: | BN: 62.6 (10.8) | | Subscale D: Psychosexual state | M-R-H Outcomes:
| | AN: N = 95 | Height, m, Mean (SD): | | Subscale E: Work and Family Relations | Good (mean score: 8 – 12): 32 (34%)
| | BN: N = 88 | AN: 1.65 (0.07) | | Study Methods | Intermediate (score 4 – < 8): 51 (54%)
| | Reasons for loss to FU: | BN: 1.65 (0.06) | | Evaluation in person or by telephone annually. | Poor (score 0 – < 4) 12 (13%)
| | Anorexia: 3 deaths, of which, 2 related to ED | BMI, Mean (SD): | | Statistical Methods | BN
| | BN: 2 lost, reason NR | AN: 16.5 (1.9) | | Dependent variable: Total scores from M-R-H scales at 5 yrs | Dx at 5 yrs:
| | Analysis Sample Size at FU: | BN: 23.1 (3.9) | | Multiple Regression | AN: 1 (1%)
| | AN: N = 92 | Duration of ED, yrs: | | M-R-H Subscales: | BN: 7 (8%)
| | BN: N = 86 | AN: 7.4 (7.0) | | Subscale A: Dietary and eating patterns, body concern, and body wt | EDNOS: 11 (13%)
| | | BN: 6.4 (4.7) | | Subscale B: Menstrual pattern | No ED: 65 (74%)
| | | AN subtype at initial assessment: | | Subscale C: Mental State | Unknown: 4 (5%)
| | | Abstainers: 59% | | Subscale D: Psychosexual state | Died: 0
| | | Binge-purgers: 41% | | Subscale E: Work and Family Relations | M-R-H Outcomes:
| | | | | | Good: 67 (76%)
| | | | | | Intermediate (score 4 – < 8): 17 (19%)
| | | | | | Poor (score 0 – < 4) 2 (2%)
| | | | | | Unknown: 2 (2%)
| | | | | | Multivariate Results
| | | | | | Predictors of higher M-R-H total mean score at 5 yrs:
| | | | | | AN:
| | | | | | Model 1
| | | | | | Age (P = 0.48)
| | | | | | M-R-H subscale A at baseline (P = 0.02) pos assoc.
| | | | | | M-R-H subscale B at baseline (P = 0.11)
| | | | | | M-R-H subscale C at baseline (P = 0.13)
| | | | | | M-R-H subscale D at baseline (P = 0.23)
| | | | | | M-R-H subscale E at baseline (P = 0.17)
| | | | | | Duration of Illness (yrs) (P = 0.18)
| | | | | | BMI at baseline (P = 0.08) pos assoc
| | | | | | Goodness of fit model (P < 0.0001), R2 = 0.0.33
| | | | | | Model 2
| | | | | | Disability adjustment scale, subscale 2 at baseline (P = 0.0006) neg assoc
| | | | | | Flinders Medical Centre Symptom Score at baseline (P = 0.03) neg assoc
| | | | | | Body Attitudes Questionnaire Subscales: Attractiveness at 6 mo (P = 0.008) pos assoc
| | | | | | Change in salience of wt and shape over first 6 mos (P = 0.024) pos assoc
| | | | | | Goodness of fit model (P < 0.0001), R2 = 0.25
| | | | | | Descriptive Results
| | | | | | BN:
| | | | | | Model 1
| | | | | | Age (P = 0.47)
| | | | | | M-R-H subscale A at baseline: (P = 0.01) neg assoc
| | | | | | M-R-H subscale B at baseline (P = NS)
| | | | | | M-R-H subscale C at baseline (P = NS)
| | | | | | M-R-H subscale D at baseline (P = NS)
| | | | | | M-R-H subscale E at baseline (P = NS)
| | | | | | Duration of Illness (yrs) (P = NS)
| | | `` | | | BMI at baseline (P = NS)
| | | | | | Goodness of fit model (P < 0.056); R^2^ = 0.085
| | | | | | Model 2
| | | | | | Disability adjustment scale, subscale 2 at recruitment (P = 0.009) neg assoc
| | | | | | Body Attitudes Questionnaire Subscales:
| | | | | | Feeling fat at recruitment (P = 0.02) neg assoc
| | | | | | Attractiveness at 6 mo (P = 0.001) pos assoc
| | | | | | Change in Zung Depression over first 6 mos (P = 0.0003) pos assoc
| | | | | | Goodness of fit model (P < 0.0001), R^2^ = 0.31
Authors, yr: | To assess and compare the long-term outcomes of patients with BN and identify predictors of outcomes. | Inclusion: | Mean number of binge days per 28 days at baseline (SD): | Score: | Treatment: | Descriptive Findings
Fairburn et al., 1995 | | Female, over 17 yrs of age, BN according to Russell criteria, wt > 79% of matched mean wt (Fairburn et al., 1986) For prior 6 mos, met criteria for BN (DSM IIII-R); aged 17 yrs or older; BMI > 17 (Fairburn et al., 1991) | 24.8 (18.5) | Fair | Analysis combines samples drawn from 2 similar RCTs that compared effectiveness of various psychotherapy techniques for the tx of BN symptomatology (i.e., CBT, BT, FIT = focal interpersonal therapy). | Eating Disorder Diagnostic Status at FU (%):
Design: | | Exclusion: | Mean number of self-induced vomiting episodes per 28 days at baseline (SD): | Method of dx: | Study 1: Short term psychological tx (CBT) administered in 19 sessions over 18 wks | AN: 3%
Case series | | Co-existing major psychiatric disorder other than depressive, anxiety, or obsessional state, current physical dependence on alcohol or drugs, need for hospitalization, on-going tx from another source, not available through 1 yr FU (Fairburn et al., 1986) Concurrent AN (Fairburn et al., 1991) | 31.9 (38.8) | EDE with an experienced clinician based on DSM IV criteria for eating disorders | Study 2: Either CBT, BT or FIT | BN: 19%
Comparison Group: | | Recruitment: | Mean number of laxative misuse episodes per 28 days at baseline (SD): | Sections from the SCID (DSM III-R version) were used to assess for mood, anxiety, and psychoactive substance use disorders | Study Methods | EDNOS: 24%
No | | Tx referrals from general practitioners and psychiatrists within community (Oxfordshire, England) | 4.3 (10.0) | Funding: | FU participants did not have to complete tx. At FU, participants administered EDE, portions of SCID, Brief Symptom Inventory (for general psychiatric symptoms), and Adult Personality Functioning Assessment interview (for dimensions of social functioning). Each participant's physical hth and medical hx also queried at time of the FU interview. | Psychiatric Status at FU:
Location: | | Recruited for first trial 1982-1984: N = 24 | Body wt at baseline, kg (SD): | United Kingdom Medical Research Council; Wellcome Trust | Statistical Analyses | Major depressive disorder: N = 8
Oxford, England | | Recruited for second trial 1985-1988: N = 75 | 60.6 (10.1) | | Both parametric and nonparametric tests used to evaluate sig diffs in variables of interest. Forward stepwise regression analyses performed to test for sig predictors of outcome. A 3x4 repeated measures ANOVA conducted to identify any sig tx effects on outcome. Log-odds models of tx were computed. | Anxiety: N = 16
Mean Yrs followed (SD): 5.8 (2.0) | | Sample Size: | BMI at baseline, kg/m ^ 2 ^ (SD): | | | Substance use: N = 3
| | Initial sample: | 22.0 (3.1) | | | AN/BN (60%) versus non-AN/BN (19%) (P < 0.001) Higher rates of general psychiatric disorders in the ED group
| | Total = 99 | Mean Age at FU, yrs (SD): | | | Remission Status (no DSM ED) at 12-mo and 6-yr FU (%):
| | Trial 1: N = 20 | 29.6 (5.5) | | | Had ED at end of tx and remission at 12 mos: 24%
| | Trial 2: N = 69 | Mean duration of ED at Baseline, yrs (SD): | | | Had ED at end of tx and remission at 6 yr: 41%
| | CBT: N = 35 | 6.7 (5.1) | | | No ED end of tx and 12 mo FU: 82%
| | FIT: N = 32 | Marital Status at FU (%): | | | No ED end of tx and 6 yr FU: 71%
| | BT: N = 22 | Single: 30% | | | Proportion with AN or BN at FU by original tx received:
| | Reasons for loss to FU: | Married/living as married: 69% | | | CBT: 20%
| | Untraceable: N = 2 | Divorced: 1% | | | FIT: 27%
| | Declined participation: N = 3 | Employment Status at FU (%): | | | BT: 22%
| | Did not respond: N = 3 | Paid: 71% | | | (P = NS)
| | Refused face-to-face or phone interview: N = 1 | Students: 9% | | | Change in Eating-related Measures from recruitment to FU:
| | Died: N = 1 | At home: 15% | | | Mean binge episodes/28 days: (P < 0.0001) reduction
| | Analysis sample: | Unemployed or disabled: 5% | | | Mean vomiting episodes/28 days (P < 0.0001) reduction
| | N = 89 (those who participated in either a face-to-face or phone FU interview) | Sex: | | | Mean laxative misuse episodes/28 days (P < 0.0001) reduction
| | | Female: 100% | | | Dietary restraint (P < 0.0001) reduction
| | | Race/ethnicity: | | | Overeating (P < 0.0001) reduction
| | | NR | | | Eating concern (P < 0.0001) reduction
| | | Mean age at study recruitment: | | | Shape concern (P < 0.0001) reduction
| | | Trial 1: 22.5 (3.8) | | | Wt concern (P < 0.0001) reduction
| | | Trial 2: 24.3 (6.0) | | | Global EDE (P < 0.0001) reduction
| | | | | | Psychiatric symptom (P < 0.0001) reduction
| | | | | | Change in Body-related Measures from Baseline to FU:
| | | | | | Body wt: (P = 0.018) increase 1.57 (6.14) kg
| | | | | | BMI (P = NS)
| | | | | | Remission Rates at FU based on original tx received:
| | | | | | CBT: OR = 3.43, 95% CI (1.77–6.63)
| | | | | | FIT: OR = 2.58, 95% CI (1.32 to 5.02)
| | | | | | BT: comparison
| | | | | | (P < 0.001)
| | | | | | Abstinence rates for key behavioral features of BN at FU by original tx received:
| | | | | | CBT: 50%
| | | | | | FIT: 52%
| | | | | | BT: 18%
| | | | | | Diff between groups (P = 0.044) at end point
| | | | | | No sig overall effect of tx on proportion of abstinent subjects and no diff effect of tx over time.
| | | | | | Mean reductions in Global EDE from baseline to FU by original tx condition (SD):
| | | | | | CBT: 2.22 (1.00)
| | | | | | FIT: 1.51 (1.00)
| | | | | | BT: 1.36 (1.32)
| | | | | | Change over time (P = 0.04)
| | | | | | Mean Eating Disorder symptom level at FU by original tx received (SD):
| | | | | | CBT: 1.27 (1.12)
| | | | | | FIT: 1.50 (1.20)
| | | | | | BT: 2.08 (1.27)
| | | | | | Diff between CBT and FIT (P = 0.049) CBT had fewer symptoms
| | | | | | Diff between CBT and BT (P = 0.015) CBT had fewer symptoms
| | | | | | Multivariate Results
| | | | | | Predictors of Current AN or BN Outcome Status (adjusted for type of tx received and duration of FU):
| | | | | | Paternal obesity: OR = 5.73, 95% CI (1.56 -21.1) (P = 0.007)
| | | | | | Premorbid obesity: OR = 4.31, 95% CI (1.35 -13.7) (P = 0.01)
| | | | | | Predictors of Change in Global EDE score Outcome:
| | | | | | Paternal obesity (P = 0.007) More severe is worse
| | | | | | Premorbid obesity:
| | | | | | (P = 0.005) More severe is worse
Authors, yr: | To assess the natural course of primary and secondary symptoms in two community-based cohorts of BN and BED participants over a 5-yr span of time. | Inclusion: | Mean Age at Baseline, yrs (SD): | Score: | Study Methods | Descriptive Findings
Fairburn et al., 2000 | | Met DSM IV diagnostic criteria for BN; Age 16 to 35 | 23.9 (5.0) | Good | Participants were contacted at 15-mo intervals over the course of a 5-yr period. They were administered a series of self-report questionnaires including the BSI, the Robson self-esteem questionnaire, and the Social Adjustment Scale. Eating disorder primary (i.e., objective bulimic episodes, self-induced vomiting, laxative misuse) and secondary (i.e., restraint, wt concern, eating concern, shape concern) symptoms were assessed through clinical interview with the EDE at each time point. | % BN at each FU Time Point (N = 74):
Companion article: | | Exclusion: | Marital status at Baseline (%): | Method of dx: | Statistical Analyses | 15-mos: 31%
Fairburn et al., 2003 | | None | Single: 59% | EDE interview | Descriptive statistics for reporting means, standard deviations, and percentages of variables at different time points. | 30-mos: 20%
Stice and Fairburn, 2003 | | Recruitment: | Married/cohabitating: 36% | Funding: | Paired t-tests and Wilcoxon matched pairs or McNemar tests to assess sig changes from recruitment to 5-yr FU. | 45-mos: 19%
Design: | | Participants were originally recruited to take part in case-control studies investigating risk factors for BN. Potential participants were initially identified from among women registered with family practices within Oxfordshire, England. | Separated/divorced: 5% | Wellcome Trust program grant; Henry J. Kaiser Family Foundation and the Center's Foundations' Fund for Research in Psychiatry | | 60-mos: 15%
Prospective cohort | | Initial Sample Size: | Social Class at Baseline (%): | | | %BED at each FU Time Point:
Comparison Group: | | At Recruitment: | 1–2: 46% | | | 15-mos: 4%
No | | BN: N = 102 | 3 (non-manual): 8% | | | 30-mos: 8%
Location: | | Reasons for loss to FU: | 3 (manual): 36% | | | 45-mos: 5%
Oxford, England | | BN: N = 1 untraceable; N = 2 nonresponders; N = 7 declined | 4–5: 9% | | | 60-mos: 7%
Yrs followed: 5 yrs | | Analysis sample size: | other: 2% | | | %AN at each FU Time Point:
| | At 5-yr FU: | Sex: | | | 15-mos: 3%
| | BN: N = 92 (90%): 87 in-person interviews, 5 phone interviews | Female: 100% | | | 30-mos: 3%
| | Data on BED sample not reported due to small sample size ( < 50) | Race/ethnicity: | | | 45-mos: 4%
| | | NR | | | 60-mos: 1%
| | | Hx of AN (%): | | | %EDNOS at each FU Time Point:
| | | 15% | | | 15-mos: 32%
| | | Current Treatment for ED (%): | | | 30-mos: 40%
| | | 10% | | | 45-mos: 35%
| | | Past Treatment for ED (%): | | | 60-mos: 32%
| | | 16% | | | % Any DSM IV ED at each FU Time Point:
| | | Mean Age at Onset of ED, yrs (SD): | | | 15-mos: 66%
| | | 15.7 (4.3) | | | 30-mos: 64%
| | | | | | 45-mos: 58%
| | | | | | 60-mos: 49%
| | | | | | % Remission (No DSM IV ED Dx):
| | | | | | 15-mos: 34%
| | | | | | 30-mos: 20%
| | | | | | 45-mos: 28%
| | | | | | 60-mos: 35%
| | | | | | % Relapse (Any DSM IV ED Dx):
| | | | | | 30-mos: 32%
| | | | | | 45-mos: 33%
| | | | | | 60-mos: 26%
| | | | | | Psychoactive Drug Use at 5-yr FU (%):
| | | | | | 3%
| | | | | | BMI Status at 5-yr FU (%):
| | | | | | < 20.0: 12%
| | | | | | 20–24.9: 53%
| | | | | | 25.0–29.9: 15%
| | | | | | > or = 30: 20%
| | | | | | Exposure to Treatment (%):
| | | | | | During FU: 28%
| | | | | | By end of FU: 40%
| | | | | | Outcomes at 5 yr FU:
| | | | | | Mean Objective Bulimic Episodes (Bingeeating) w/in last 3 mos (SD):
| | | | | | 15.3 (29.4)
| | | | | | Reduction from baseline (P < 0.001)
| | | | | | Mean Self-induced Vomiting Episodes w/in last 3 mos (SD):
| | | | | | 15.5 (42.9)
| | | | | | Reduction from baseline (P < 0.001)
| | | | | | Mean Laxative Misuse w/in last 3 mos (SD):
| | | | | | 3.4 (14.8)
| | | | | | Reduction from baseline (P < 0.001)
| | | | | | Mean EDE Restraint (SD):
| | | | | | 1.82 (1.59)
| | | | | | Reduction from baseline (P < 0.001)
| | | | | | Mean EDE Shape Concern (SD):
| | | | | | 2.55 (1.49)
| | | | | | Reduction from baseline (P < 0.001)
| | | | | | Mean EDE Wt Concern (SD):
| | | | | | 2.35 (1.50)
| | | | | | Reduction from baseline (P < 0.001)
| | | | | | Mean EDE Eating Concern (SD):
| | | | | | 0.84 (1.13)
| | | | | | Reduction from baseline (P < 0.001)
| | | | | | Mean BSI (SD):
| | | | | | 0.90 (0.77)
| | | | | | Reduction from baseline (P < 0.01)
| | | | | | Alcohol Misuse (%):
| | | | | | 26%
| | | | | | Increase from baseline (P < 0.05)
| | | | | | Mean Self-esteem (SD):
| | | | | | 42.3 (9.7)
| | | | | | Change from baseline (P = NS)
| | | | | | Mean Social Adjustment (SD):
| | | | | | 1.40 (0.28)
| | | | | | Change from baseline (P = NS)
| | | | | | Mean Wt, kg (SD):
| | | | | | 69.8 (19.2)
| | | | | | Increase from baseline (P < 0.01)
| | | | | | Mean BMI (SD):
| | | | | | 25.5 (6.4)
| | | | | | Increase from baseline (P < 0.05)
Authors, yr: | To identify predictors of persistence of BN and to test hypotheses derived from cognitive behavior theory of persistence. | Inclusion: | Mean Age at recruitment (SD): | Score: | Study Methods: | Descriptive Findings
Fairburn et al., 2003 | | Women | 23.7 (4.9) | Good | Interviewer administered EDE, Brief Symptom Inventory | Binge eating outcome classification based on binge eating behavior (N):
Companion article: | | DSM IV for BN | Sex: | Method of dx: | Statistical Methods: | Remitted: 39 (38%)
Fairburn et al., 2000 | | Exclusion: | Female: 100% | Interview using EDE | ANOVA or chi-square comparing remitted and persistent outcome groups | Persistent: 45 (44%)
Stice and Fairburn, 2003 | | None | Race/ethnicity: | Funding: | Multiple regression used for change over time analyses. | Not classified: 18 (18%) (P = NR)
Design: | | Recruitment: | NR | Wellcome Trust program grant, NIMH | Binge eating outcome classifications: | Binge eating outcome classification based on compensatory behavior (N):
Case series | | Patients in family practices in Oxfordshire, England. Screened with self-report version of the EDE. | Social class: | | Persistent: at least 2 episodes of behavior at 1 or both of last 2 assessments | Remitted: 39 (38%)
Comparison Group: | | Sample Size: | I or II (high): 47% | | Remitted: not engaged in any relevant behavior (over past 3 mos) at 2 consecutive assessments and all subsequent assessments | Persistent: 49 (48%)
No | | Sample size: N = 102 | III (middle): 45% | | Not classified | Not classified: 14 (14%) (P = NR)
Location: | | No loss to FU | IV or V (low): 9% | | Analyses compares binge eating outcomes separately based on: 1) binge eating behaviors and 2) compensatory behaviors | Relationship between remitted vs. persistent binge eating outcome (based on binge eating behaviors) and baseline variables:
England | | | Age of full BN onset: | | | Age at onset (P = NS)
Yrs followed: 5 | | | 19.0 (4.0) | | | Duration of disturbed eating: Persistent: 9.8; Remitted: 6.9 (P < 0.01)
| | | No prior tx for ED: | | | Binge eating frequency (P = NS)
| | | 82% | | | Compensatory behavior frequency (P = NS)
| | | No current tx for ED: | | | Global EDE Score (P = NS)
| | | 89% | | | Overevaluation of shape and wt: Persistent: 3.2; Remitted: 2.6 (P < 0.05)
| | | Some tx for ED during 5 yr FU: | | | Dietary restraint (P = NS)
| | | 24% | | | General psychiatric symptoms (P = NS)
| | | | | | Self-esteem (P = NS)
| | | | | | Social adjustment: Persistent: 1.5; Remitted: 1.3; (P < 0.05)
| | | | | | BMI (P = NS)
| | | | | | Proportion with hx of AN: (P = NS)
| | | | | | Proportion with hx of childhood obesity: RR = 1.9, 95% CI (1.1–3.5) (P < 0.05)
| | | | | | Proportion classified as persistent based on compensatory behavior: RR = 2.6, 95% CI (1.6–4.2) (P < 0.0001)
| | | | | | Relationship between remitted vs persistent binge eating outcome (based on compensatory behavior) and baseline variables:
| | | | | | Age at onset (P = NS)
| | | | | | Duration of disturbed eating (P = NS)
| | | | | | Binge eating frequency (P = NS)
| | | | | | Compensatory behavior frequency (P = NS)
| | | | | | Global EDE Score (P = NS)
| | | | | | Overevaluation of shape and wt (P = NS)
| | | | | | Dietary restraint (P = NS)
| | | | | | General psychiatric symptoms (P = NS)
| | | | | | Self-esteem (P = NS)
| | | | | | Social adjustment (P = NS)
| | | | | | BMI (P = NS)
| | | | | | Proportion with hx of AN: (P = NS)
| | | | | | Proportion with hx of childhood obesity (P = NS)
| | | | | | Proportion classified as having persistent course based on binge eating behavior: RR = 3.0, 95% CI (1.6–5.4) (P < 0.0001)
| | | | | | Multivariate Findings
| | | | | | Change over time:
| | | | | | Change in frequency of binge eating:
| | | | | | - Related to initial overall evaluation of shape and wt (P < 0.07); - Initial level of overevaluation of shape and wt nonsig when effects of change in dietary restraint sig controlled in model.
| | | | | | Change in level of restraint:
| | | | | | - Pos related to initial level of overevaluation of shape and wt (P < 0.01)
Authors, yr: | To describe the longer-term course and outcome of BN and to identify risk factors for an unfavorable course. | Inclusion: | Age at admission, mean (SD): | Score: | Study Methods | Descriptive Results
Fichter and Quadflieg, 2004 | | Cases: | 25.6 (6.7) | Fair | Patients were assessed at the beginning of inpatient tx, at the end of tx, at 2, 6, and 12 yr FU. | Body image, ideal of slimness, and bulimic behavior decreased in severity at 12 yr FU when compared with any previous time - point
Design: | | BN-Purging type per DSM IV (Patients reassessed in later yrs per DSM IV and were included if met diagnostic criteria at time of hospital admission) | Sex: | Method of dx: | Each FU consisted of two steps: all patients completed a questionnaire and were then contacted for an interview | (P < 0.001). Values NR
Case series | | Comparisons: | Female: 100% | Structured Interview for AN and Bulimic Syndromes (SIAB-EX) | Analytic Strategy | BMI:
Comparison Group: | | Females, aged 18–30, never suffered from eating disorder | Race/ethnicity: | Funding: | MANOVA with repeated measures based on five time points. Post hoc Scheffe range tests when appropriate. | End of tx: 21.1 (4.5)
Yes | | Exclusion: | NR | Wilhelm Sander-Stiftung, Munich, Germany; German Bundesministerium fur Bildung Forschung und Technologie (BMBF) | Logistic regression with all predictors entered in step one. | 12 yr FU: 22.1 (5.3)
Location: | | None reported | Length of inpatient tx, days, mean (SD): | | Standardized mortality ratio computed on the basis of expected deaths between 1/87 and 9/99 in the West German female population controlled by age groups. | Diff over time (P = NR)
Upper Bavaria, Germany | | Recruitment: | 95.5 (42.6) | | | Obesity (BMI > 30), N (%):
Yrs followed: 12 | | Cases: Of 635 consecutively admitted patients with eating disorders between 9/85 – 6/88, 196 met inclusion criteria. | | | | 2 yr FU: 12/192 (6.3%)
| | Comparisons: general population | | | | 6 yr FU: 11/182 (6.0%)
| | Sample Size: | | | | 12 yr FU: 14/163 (8.6%)
| | Cases: | | | | Diff over time (P = NR)
| | Began tx: N = 196 | | | | BMI < 17.5, N (%):
| | Completed 2 yr FU: 194/196 (99%) | | | | 2 yr FU: 12/192 (6.3%)
| | Completed 6 yr FU: 185/194 alive (95.4%) | | | | 6 yr FU: 12/182 (6.6%)
| | Completed 12 yr FU: 163/192 alive (84.9%) | | | | 12 yr FU: 8/163 (4.9%)
| | Comparisons: N = 202 | | | | Diff over time (P = NR)
| | Reasons for Loss to FU | | | | EDI, drive for thinness:
| | Unable to reach: N = 3 | | | | Baseline: 12.5 (5.5)
| | Refused participation: N = 26 | | | | End of tx: 6.8 (5.5)
| | | | | | 2 yr FU: 7.5 (6.0)
| | | | | | 6 yr FU: 5.1 (5.7)
| | | | | | 12 yr FU: 3.3 (4.2)
| | | | | | Diff over time (P < 0.001)
| | | | | | EDI, bulimia:
| | | | | | Baseline: 12.5 (4.7)
| | | | | | End of tx: 3.3 (4.3)
| | | | | | 2 yr FU: 6.1 (5.8)
| | | | | | 6 yr FU: 4.0 (5.1)
| | | | | | 12 yr FU: 2.4 (4.0)
| | | | | | Diff over time (P < 0.001)
| | | | | | EDI, body dissatisfaction:
| | | | | | Baseline: 16.7 (8.5)
| | | | | | End of tx: 10.4 (9.2)
| | | | | | 2 yr FU: 12.2 (9.1)
| | | | | | 6 yr FU: 10.2 (8.4)
| | | | | | 12 yr FU: 8.9 (8.2)
| | | | | | Diff over time (P < 0.001)
| | | | | | EDI, perfectionism:
| | | | | | Baseline: 6.8 (4.8)
| | | | | | End of tx: 5.4 (3.7)
| | | | | | 2 yr FU: 5.7 (3.9)
| | | | | | 6 yr FU: 5.2 (3.7)
| | | | | | 12 yr FU: 4.7 (3.3)
| | | | | | Diff over time (P < 0.001)
| | | | | | Diagnostic Outcome at 2 yrs (N = 162), N (%):
| | | | | | Recovered and no ED dx: 86 (53.1%)
| | | | | | AN-restricting: 1 (0.6%)
| | | | | | AN-binge/purge type: 2 (1.2%)
| | | | | | BN-purging type: 48 (29.6%)
| | | | | | BN-nonpurging type: 7 (4.3%)
| | | | | | BED: 0
| | | | | | EDNOS: 12 (7.4%)
| | | | | | Deceased: 0
| | | | | | Diagnostic Outcome at 6 yrs (N = 162), N (%):
| | | | | | Recovered and no ED dx: 108 (66.7%)
| | | | | | AN-restricting: 2 (1.2%)
| | | | | | AN-binge/purge type: 5 (3.1%)
| | | | | | BN-purging type: 34 (21.0%)
| | | | | | BN-nonpurging type: 1 (0.6%)
| | | | | | BED: 2 (1.2%)
| | | | | | EDNOS: 2 (1.2%)
| | | | | | Deceased: 2 (1.2%)
| | | | | | Diagnostic Outcome at 12 yrs (N = 162), N (%):
| | | | | | Recovered and no ED dx: 107 (66.0%)
| | | | | | AN-restricting: 1 (0.6%)
| | | | | | AN-binge/purge type: 2 (1.2%)
| | | | | | BN-purging type: 16 (9.9%)
| | | | | | BN-nonpurging type: 1 (0.6%)
| | | | | | BED: 3 (1.9%)
| | | | | | EDNOS: 22 (13.6%)
| | | | | | Deceased: 4 (2.5%)
| | | | | | Standard Mortality Ratio:
| | | | | | 2.36, 95% CI (0.05 – 4.67)
| | | | | | Bingeing at 12 yr FU:
| | | | | | At least twice per wk: 22.1%
| | | | | | Less than twice per wk: 18.4%
| | | | | | Not binged in the preceding three mos: 59.5%
| | | | | | Vomiting at 12 yr FU:
| | | | | | At least twice per wk: 20.8%
| | | | | | Less than twice per wk: 11.3%
| | | | | | Not at all: 67.9%
| | | | | | SIAB-EX Score at 12 yr FU:
| | | | | | Total scale:
| | | | | | BN recovered (N = 114): 0.5 (0.3)
| | | | | | BN all (N = 158): 0.6 (0.4)
| | | | | | Healthy Comparisons (N = 202): 0.3 (0.2)
| | | | | | Diff between BN recovered and healthy comparisons (P < 0.001)
| | | | | | BN recovered greater than comparisons
| | | | | | Diff between BN all and healthy comparisons (P < 0.01)
| | | | | | BN all greater than comparisons
| | | | | | Amenorrhea:
| | | | | | Beginning of tx: 18.1%
| | | | | | 12 yr FU: 1.6%
| | | | | | Psychiatric Co-morbidity at 12 yr FU:
| | | | | | Lifetime 79.7%; current 1 mo: 41.1%
| | | | | | Mood disorders: Lifetime 69.0%; current 1 mo: 16.5%
| | | | | | Major depression: Lifetime 58.2%; current 1 mo: 10.8%
| | | | | | Dysthymic: Lifetime 14.6%; current 1 mo: 5.1%
| | | | | | Anxiety: Lifetime 36.1%; current 1 mo: 22.2%
| | | | | | Substance use: Lifetime 36.1%; current 1 mo: 14.6%
| | | | | | Borderline Personality Disorder: 9.5%
| | | | | | Additional Treatment
| | | | | | Inpatient tx days, mean (SD):
| | | | | | 2 yr FU: 15.1 (37)
| | | | | | 2 – 6 yr FU: 9.5 (29)
| | | | | | 6 – 12 yr FU: 6.4 (14)
| | | | | | Patients who received at least one inpatient tx during 12 yrs:
| | | | | | 140/158 (88.6%)
| | | | | | Admissions per yr to any type of institution, N:
| | | | | | 2 yr FU: 31.5
| | | | | | 2 – 6 yr FU: 22
| | | | | | 6 – 12 yr FU: 18.5
| | | | | | Multivariate Results
| | | | | | Predictors of any ED at FU:
| | | | | | Lifetime psychiatric comorbidity predicted poor outcome:
| | | | | | 2 yr: OR: 2.53, 95% CI (1.06 – 6.06) (P < 0.05)
| | | | | | 6 yr: OR: 2.81, 95% CI (1.02 – 7.71) (P < 0.05)
| | | | | | 12 yr: OR: 2.52, 95% CI (0.93 – 6.80) (P = NS)
| | | | | | With PSR as outcome criterion:
| | | | | | 2 yr: OR: 3.55, 95% CI (1.34 – 9.41) (P < 0.05)
| | | | | | 6 yr: OR: 2.40, 95% CI (0.88 – 6.58) (P = NS)
| | | | | | 12 yr: OR: 3.71, 95% CI (1.16 – 11.91) (P < 0.05)
| | | | | | Positive hx of AN predicted poor outcome:
| | | | | | 2 yr (P = NS) (values NR)
| | | | | | 6 yr: OR: 2.05, 95% CI (0.94 – 4.45) (P = NS)
| | | | | | 12 yr (P = NS) (Values NR)
| | | | | | With PSR as outcome criterion:
| | | | | | 2.38, 95% CI (1.03 – 5.50) (P < 0.05)
| | | | | | Childhood obesity
| | | | | | 2 yr: OR: 2.86, 95% CI (1.02 – 8.06) (P < 0.05)
| | | | | | Other yrs (P = NS)
| | | | | | Higher age at onset of ED
| | | | | | 12 yr: OR: 1.01, 95% CI (1.01 – 1.16) (P < 0.05)
| | | | | | Other yrs (P = NS)
| | | | | | Longer duration of ED:
| | | | | | All yrs (P = NS)
| | | | | | Higher frequency of binges:
| | | | | | All yrs: (P = NS)
| | | | | | Having undergone tx for ED prior to index tx:
| | | | | | All years (P = NS)
Authors, year: | To assess the 2 and 6 yr course and outcomeof BN among a group of women with BN-purging type. | Inclusion: | Mean Age at inpt admission (SD): | Score: | Study Methods: | Results:
Fichter and Quadflieg, 1997 | | Females | 25.6 (6.7) yrs | Fair | Patients assessed at admission to inpt, discharge from inpt, 2 yrs, 6 yrs. | Descriptive
Design: | | DSM-IV for BN-purging type | Sex: | Method of diagnosis: | For FU, pts sent questionnaire packet to complete.After packet returned, interview conducted by specially trained psychologists and physicians.Those not able to do long interview, given shorter version.Long interview were face to face or by phone, short by phone only. | Binge 2 times per wk (self-report):
Case Series | | Admitted to inpatient ED tx | Female 100% | Specially trained psychologists or physician used. | Questionnaires: | Tx start: 100%
Comparison Group: | | Exclusion: | Race/ethnicity: | DSM-IV criteriafor BN based on interview and/or SIAB data. | SIAB, EDI, AN Inventory for Self-Rating, BN version of PSR, SCL-90, Complaint List, BDI, Munich Diagnostic Checklist for DSM-III-R | Discharge: 46%
No | | None stated | NR | Funding: | Assessments: | 2 yr and 6 yr FU: 42%
Location: | | Recruitment: | Duration of sx before tx start (SD): | Wilhelm-Sander-Stiftung | 2.0 (0.7) yrs and 6.2 (0.9) yrs | Vomiting (≥ 2 times per wk):
Upper Bavaria, Germany | | Females who where dx'ed with BN and admitted to ED inpt program at Klinik Roseneck in Upper Bavaria Germany from 1985-1988. | 8.1 (4.9) yrs | | Statistical Method: | Tx start: 88.1%
Yrs followed: | | Sample Size: | Age of onset (SD): | | Repeated measures MANOVAs | Discharge: 49.7%
6.2 (0.9) from end of tx | | Initial (N = 196) | 17.6 (4.8) yrs | | Pairwise t tests | 2 yr FU: 42.7%
| | Finished tx (N=166) | Inpatient days (SD): | | Longitudinal comparisons used sets complete for all time points. | 6 yr FU: 33.6%
| | 2 yr FU (N = 184) | 95.5 (43) | | Outcomes | Mean BMI (SD):
| | 6 yr FU (N=185) | Discharge Status: | | SIAB, supplemented by PSR | Tx start : 21.5 (5.0)
| | Loss to FU at 6 yr: | Normal: 166 | | Global outcomes:aggregate of 10 outcome categories including overconcern with eating and wt, binge attacks, counterregulatory measures, body wt, depression, obsessions, anxiety, substance abuse, sexual problems, problems in social behavior Good - outcome of 1 or 0 Intermediate - outcome of 2 Poor - outcome of 3–4 | Discharge from tx : 21.1 (4.4)
| | Death (N=2) | Premature: 10 | | PSR | 2 yr FU: 21.5 (4.3)
| | (pneumonia = 1 | By team: 1 | | Good - outcome of 1 or 2 | 6 yr FU: 21.8 (4.6)
| | pneumonia & heart problems = 1) | By mutual agreement: 18 | | Intermediate - outcome of 3–4 | Wt outcome:
| | Not reached (N=6) | Improvement at discharge: | | Poor - outcome of 5–6 | Good: (19<BMI<30): 73.9%
| | Refused to participate (N=3) | Sig improvement: 47 (24.1%) | | | Intermediate: (BMI 30–40, or 17.5–19): 17.0%
| | | Marked improvement: 77 (39.5%) | | | Poor: (BMI< 17.5, BMI > 40): 9.1%
| | | Slight improvement: 60 (30.8%) | | | Dx outcome (DSM-IV):
| | | Unchanged: 9 (4.6%) | | | At 2 yr FU:
| | | Slightly worse: 1 (0.5%) | | | BN:35.8%
| | | Marked worse: 1 (0.5%) | | | AN:1.6%
| | | Education: | | | BED: 0%
| | | < 9 yrs: 1% | | | EDNOS: 8.0%
| | | ≥ 9 yrs:69% | | | No ED dx: 54.5%
| | | ≥ 13 yrs:25% | | | At 6 yr FU:
| | | University degree: | | | BN: 21.4%
| | | 5% | | | AN: 3.7%
| | | | | | BED: 1.1%
| | | | | | EDNOS: 1.6%
| | | | | | No ED dx: 71.1%:
| | | | | | PSR ED sx ratings (N):
| | | | | | At 2 yr FU:
| | | | | | Marked sx:29
| | | | | | Partial remission: 25
| | | | | | Residual sx: 25
| | | | | | Usual self: 20
| | | | | | At 6 yr FU:
| | | | | | Marked sx: 25
| | | | | | Partial remission: 26
| | | | | | Residual sx: 45
| | | | | | Usual self:37
| | | | | | Global outcome at 6 yr FU:
| | | | | | Good: 59.9%
| | | | | | Intermediate: 29.4%
| | | | | | Poor: 9.6%
| | | | | | Deceased: 1.1%
| | | | | Study Methods: | Change over time EDI
| | | | | Patients assessed at admission to inpt, discharge from inpt, 2 yrs, 6 yrs. | Total
| | | | | For FU, pts sent questionnaire packet to complete.After packet returned, interview conducted by specially trained psychologists and physicians.Those not able to do long interview, given shorter version.Long interview were face to face or by phone, short by phone only. | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | Questionnaires: | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | SIAB, EDI, AN Inventory for Self-Rating, BN version of PSR, SCL-90, Complaint List, BDI, Munich Diagnostic Checklist for DSM-III-R | Discharge vs 2 yr FU: (P < 0.01) Worsened
| | | | | Assessments: | Discharge vs 6 yr FU: (P = NS)
| | | | | 2.0 (0.7) yrs and 6.2 (0.9) yrs | 2 yr FU vs 6 yr FU: (P < 0.0001) Improved
| | | | | Statistical Method: | Drive for Thinness
| | | | | Repeated measures MANOVAs | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | Pairwise t tests | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | Longitudinal comparisons used sets complete for all time points. | Disharge vs 2 yr FU: (P = NS)
| | | | | Outcomes | Discharge vs 6 yr FU: (P < 0.05) Worsened
| | | | | SIAB, supplemented by PSR | 2 yr FU vs 6 yr FU: (P < 0.001) Improved
| | | | | Global outcomes:aggregate of 10 outcome categories including overconcern with eating and wt, binge attacks, counterregulatory measures, body wt, depression, obsessions, anxiety, substance abuse, sexual problems, problems in social behavior Good - outcome of 1 or 0 Intermediate - outcome of 2 Poor - outcome of 3–4 | Bulimia:
| | | | | PSR | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | Good - outcome of 1 or 2 | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | Intermediate - outcome of 3–4 | Discharge vs 2 yr FU: (P < 0.001) Worsened
| | | | | Poor - outcome of 5–6 | Discharge vs 6 yr FU: (P < 0.05) Worsened
| | | | | | 2 yr FU vs 6 yr FU: (P < 0.001) Improved
| | | | | | Body dissatisfaction
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P = NS)
| | | | | | Discharge vs 6 yr FU: (P = NS)
| | | | | | 2 yr FU vs 6 yr FU: (P < 0.001) Improved
| | | | | | Ineffectiveness
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P < 0.001) Worsened
| | | | | | Discharge vs 6 yr FU: (P = NS)
| | | | | | 2 yr FU vs 6 yr FU: (P < 0.001) Improved
| | | | | | Perfectionism
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.01) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P = NS)
| | | | | | Discharge vs 6 yr FU: (P = NS)
| | | | | | 2 yr FU vs 6 yr FU: (P = NS)
| | | | | | Change over time AN SIAB
| | | | | | Total
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P < 0.01) Worsened
| | | | | | Discharge vs 6 yr FU: (P < 0.001) Improved
| | | | | | 2 yr FU vs 6 yr FU: (P < 0.001) Improved
| | | | | | Body image and ideal of slimness
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P = NS)
| | | | | | Discharge vs 6 yr FU: (P < 0.05) Improved
| | | | | | 2 yr FU vs 6 yr FU: (P < 0.01) Improved
| | | | | | Depression
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P < 0.01) Worsened
| | | | | | Discharge vs 6 yr FU: (P < 0.001) Improved
| | | | | | 2 yr FU vs 6 yr FU: (P < 0.001) Improved
| | | | | | Anxieties and obsessions
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P < 0.01) Worsened
| | | | | | Discharge vs 6 yr FU: (P < 0.001) Improved
| | | | | | 2 yr FU vs 6 yr FU: (P < 0.001) Improved
| | | | | | Bulimic behavior
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P < 0.01) Worsened
| | | | | | Discharge vs 6 yr FU: (P < 0.001) Improved
| | | | | | 2 yr FU vs 6 yr FU: (P < 0.001) Improved
| | | | | | Laxative abuse
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P < 0.01) Improved
| | | | | | Discharge vs 6 yr FU: (P < 0.001) Improved
| | | | | | 2 yr FU vs 6 yr FU: (P = NS)
| | | | | | Psychiatric comorbidities at 2 yr FU (N=184) and 6 yr FU (N=165)
| | | | | | Borderline Personality Disorder
| | | | | | 2 yr FU: 5.4%
| | | | | | 6 yr FU: 3.6%
| | | | | | Lifetime: 8.9%
| | | | | | Substance abuse (excluding laxatives)
| | | | | | 2 yr FU: 23.9%
| | | | | | 6 yr FU: 21.2%
| | | | | | Lifetime: 41.6%
| | | | | | Mood disorders
| | | | | | 2 yr FU: 29.9%
| | | | | | 6 yr FU: 45.5%
| | | | | | Lifetime: 55.3%
| | | | | | Anxiety disorders
| | | | | | 2 yr FU: 13.0%
| | | | | | 6 yr FU: 31.5%
| | | | | | Lifetime: 34.2%
| | | | | | SCL-90: general psychopathology (N=118)
| | | | | | Global severity index
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P < 0.001) Worsened
| | | | | | Discharge vs 6 yr FU: (P < 0.001) Improved
| | | | | | 2 yr FU vs 6 yr FU: (P = NS)
| | | | | | Positive symptom total (PST)
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P < 0.001) Worsened
| | | | | | Discharge vs 6 yr FU: (P < 0.001) Improved
| | | | | | 2 yr FU vs 6 yr FU: Improved
| | | | | | Positive Symptom Distress Index (PSDI)
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P < 0.001) Worsened
| | | | | | Discharge vs 6 yr FU: (P < 0.001) Improved
| | | | | | 2 yr FU vs 6 yr FU: (P = NS)
| | | | | | Somatization
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P < 0.01) Worsened
| | | | | | Discharge vs 6 yr FU: (P= NS)
| | | | | | 2 yr FU vs 6 yr FU: (P = NS)
| | | | | | Obsessive-compulsive symptoms
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P < 0.001) Worsened
| | | | | | Discharge vs 6 yr FU: (P = NS)
| | | | | | 2 yr FU vs 6 yr FU: (P < 0.001) Improved
| | | | | | Depression
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P < 0.001) Worsened
| | | | | | Discharge vs 6 yr FU: (P = NS)
| | | | | | 2 yr FU vs 6 yr FU: (P < 0.01) Improved
| | | | | | Anxiety
| | | | | | Beginning of tx vs 2 yr FU: (P < 0.001) Improved
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 2 yr FU: (P < 0.01) Worsened
| | | | | | Discharge vs 6 yr FU: (P < 0.001) Improved
| | | | | | 2 yr FU vs 6 yr FU: (P < 0.01) Improved
| | | | | | BDI
| | | | | | Beginning of tx vs 6 yr FU: (P < 0.001) Improved
| | | | | | Discharge vs 6 yr FU: (P = NS)
Authors, yr: | To determine predictors of serious suicide attempts in women with AN and BN. | Inclusion: | Mean Age: | Score: | Study Methods | Descriptive Results
Franko et al., 2004 | | Female, English speaking, meet full criteria for AN and/or BN, at least 12 yrs of age, reside within 200 miles of the study site. | 24.8 (range: 13 to 45) at entry to the study. | Good | FU interviews conducted every 6 – 12 mos in person when possible. | Baseline, Reported hx of suicide attempts prior to study entry:
Design: | | Exclusion: | Sex: | Method of dx: | Statistical Methods | AN: 30.1%
Case series | | Organic brain syndrome or terminal illness. | Female:100% | LIFE-EAT-II and the PSR scale | Non-parametric tests to examine diff on self-report measures administered at intake between subjects who made suicide attempts and those who did not. | BN: 22.7%
Comparison Group: | | Recruitment: | Race/ethnicity: | Funding: | Kaplan-Meier survival analyses to determine time to first suicide attempt, and time-varying proportional hazards (Cox) regression models used to determine influence of baseline and course variables on time to first suicide attempt. | Rates of suicide attempts:
No | | 554 consecutive women who sought tx for eating disorder at Massachusetts General Hospital or other Boston area clinics between October 1987 and June 1990. | Non-Caucasian: 4% | NIMH, Rubenstein Foundation, and Harvard Eating Disorders Care | Multiple regression to predict time to first suicide attempt. | AN: 30 (22.1%)
Location: | | Sample Size | Mean duration of illness: | | | BN: 12 (10.9%)
Massachusetts, USA | | Initial Sample: | 6.7 yrs (range: 3 mos – 21 yrs) | | | Death from suicide: N = 4 (none had a previous suicide attempt)
Yrs followed: Mean: 8.6 | | Met dx criteria: N = 268 | | | | Diff between baseline self report measures for suicide attempters and non-attempters, mean (SD):
| | Agreed to participate: N = 229 | | | | AN
| | Additional participants identified: N = 21 | | | | EDI, drive for thinness (P = NS)
| | Reasons for loss to FU: | | | | EDI, Bulimia (P = NS)
| | Drop out prior to first FU: N = 4 | | | | EDI, body dissatisfaction (P = NS)
| | Analysis Sample | | | | EDI, ineffectiveness:
| | N = 246 | | | | - attempters: 15.2 (8.6); - non-attempters: 11.4 (7.8); - (P = 0.04); Attempters did worse
| | AN-Restricting: 51 | | | | EDI, perfectionism (P = NS)
| | AN-Binge Purge: 85 | | | | EDI, interpersonal distrust (P = NS)
| | BN: 110 | | | | EDI, interoceptive awareness (P = NS)
| | | | | | EDI, maturity fears (P = NS)
| | | | | | BDI:
| | | | | | attempters: 27.6 (12.1)
| | | | | | non-attempters: 22.7 (11.3)
| | | | | | (P = 0.05). Attempters had greater depression.
| | | | | | Symptom distress (P = NS)
| | | | | | Global severity index (P = NS)
| | | | | | Positive symptom total (P = NS)
| | | | | | BN
| | | | | | EDI, drive for thinness (P = NS)
| | | | | | EDI, Bulimia (P = NS)
| | | | | | EDI, body dissatisfaction (P = NS)
| | | | | | EDI, ineffectiveness:
| | | | | | - attempters: 14.6 (7.1); - non-attempters: 8.4 (6.1); - (P = 0.007); Attempters did worse
| | | | | | EDI, perfectionism (P = NS)
| | | | | | EDI, interpersonal distrust:
| | | | | | - attempters: 7.1 (4.0); - non-attempters: 4.5 (3.4); - (P = 0.04). Attempters did worse.
| | | | | | EDI, interoceptive awareness
| | | | | | - attempters: 17.7 (7.6); - non-attempters: 10.9 (5.9); - (P = 0.003). Attempters did worse
| | | | | | EDI, maturity fears:
| | | | | | - attempters: 7.6 (7.3); - non-attempters: 3.7 (4.3); - (P = 0.03). Attempters did worse.
| | | | | | BDI:
| | | | | | attempters: 27.0 (11.7)
| | | | | | non-attempters: 19.6 (9.5)
| | | | | | (P = 0.03)
| | | | | | Attempters had greater depression.
| | | | | | Symptom distress:
| | | | | | - attempters: 2.2 (0.46); - non-attempters: 1.9 (1.4); - (P = 0.006). Attempters did worse
| | | | | | Global severity index:
| | | | | | - attempters: 1.6 (0.49); - non-attempters: 1.0 (0.54); - (P = 0.002). Attempters did worse.
| | | | | | Positive symptom total:
| | | | | | - attempters: 64.0 (11.7); - non-attempters: 47.7 (18.0); - (P = 0.003). Attempters did worse.
| | | | | | Multivariate Results
| | | | | | Predictors of time to first suicide attempt during course of study-hypothesis testing results:
| | | | | | AN
| | | | | | Hx of suicide attempt at intake (P < 0.009)
| | | | | | Eating disorder symptomatology (P = NS)
| | | | | | Severity of drug use (P < 0.01)
| | | | | | Alcohol use (P = NS)
| | | | | | BN
| | | | | | Laxative use (P < 0.05)
| | | | | | Hx of drug use disorder prior to start of the study (P < 0.01)
| | | | | | AN
| | | | | | Hx of suicide attempt at intake: HM = 1.09, 95% CI (1.31 – 6.71)
| | | | | | (P = 0.009); Shorter time to first attempt
| | | | | | Drug use: HM = 0.92, 95% CI (1.40 – 4.52) (P = 0.010); Greater use shorter time
| | | | | | Individual therapy: HM = 3.54, 95% CI (1.20 – 10.42) (P = 0.013); Yes, shorter time
| | | | | | Neuroleptic meds: HM = 5.03, 95% CI (1.50 – 16.86) (P = 0.02); Yes, shorter time
| | | | | | Age of onset: HM = 1.06, 95% CI (1.00 – 1.12) (P = 0.05); Older age, shorter time
| | | | | | Group therapy: HM = 2.35, 95% CI (1.00 – 5.53) (P = 0.06)
| | | | | | Severity of depression: HM = 1.21, 95% CI (0.99 – 1.50) (P = 0.06)
| | | | | | Alcohol use: HM = 1.54, 95% CI (0.99 – 1.04) (P = 0.08)
| | | | | | BN
| | | | | | Group therapy: HM = 11.32, 95% CI (2.33 – 55.02) (P = 0.002); Yes, shorter time
| | | | | | Age of onset: HM = 0.82, 95% CI (0.70 – 0.97) (P = 0.008); Younger age, shorter time
| | | | | | Hx of drug use disorder: HM = 8.94, 95% CI (1.87 – 42.77) (P = 0.009); Greater hx, shorter time
| | | | | | Individual therapy: HM = 10.39, 95% CI (1.03– 105.12) (P = 0.020); Yes, shorter time
| | | | | | Paranoid personality disorder at intake: HM = 66.5, 95% CI (3.60 – 129.84) (P = 0.020); Yes, shorter time
| | | | | | Severity of laxative use: HM = 1.21, 95% CI (1.50 – 46.30) (P = 0.022); More, shorter time
| | | | | | Psychiatric hospitalization: HM = 10.75, 95% CI (1.16 – 99.86) (P = NS)
Authors, yr: | To determine the clinical and nutritional variables associate with menstrual disturbance in women presenting for tx for BN at 1 yr FU. | Inclusion: | Mean Age, yrs (SD) | Score: | Intervention: | Descriptive Results:
Gendall et al., 2000 | | Women, age 17–45, DSM IV criteria for BN, purging type | 26.2 (6.2) | Good | Outpatient tx testing use of exposure with response prevention to cognitive behavioural therapy for BN | Women with vs. without regular menses - 1 yr FU
Design: | | Exclusion: | Sex: | Method of dx: | Study Methods: | Women with irregular menses - 30.5%
Case series | | AN, BMI < 17 or >30 kg/m^2^ Current use of psychoactive meds, hysterectomy or using oral contraceptives | Female 100% | Clinician administered SCID for DSM III-R, Global Assessment of Functioning, Structured clinical interview for core BN symptoms in past fortnight | Assessed PreTx and at 1 yr Post-Tx. | Irregular menses at 1 yr FU associated with following baseline measures:
Comparison Group: | | Recruitment: | Race/ethnicity: | Funding: | At pre-Tx and 1 yr FU clinician administered SCID-III-R, Global Assessment of Functioning Scale, structured clinical interview of core BN sx., Hamilton Depression Rating Scale (HDRS) adjusted for wt. and appetite items. Body wt and height measures. | Low past min. body wt. (P = 0.05)
No | | Women participating in outpatient tx trial recruited through media adsgeneral practitioner and mental health worker referrals | NR | NR | Statistical Method: | Greater max.-min. wt diff (P = 0.001)
Location: | | Sample Size: | Mean BMI (kg/cm ^ 2 ^ ) (SD) | | Log transformation of non-normal distributions | Current smoking (P = 0.03)
New Zealand | | N = 82 | 23.0 (2.7) | | ANOVA | At FU, dx of major depression in past 6 mos:
Yrs followed: 1 | | Loss to FU: | Age Menarche (SD) | | Chi-Square | Regular menstruators: 18.5%
| | None | 13.0 (1.5) | | Logistic regression analyses | Irregular menstuators: 44%
| | | PreTx Irregular Menses: | | Outcomes | (P = 0.03)
| | | 45.1% | | Irregular menstruators: Absent or irregular menstrual cycles within past 3 mos. | Irregular at PreTx became regular at FU: 56.8%
| | | Hx of Amenorrhea | | | Multivariate Results
| | | 46.3% | | | Sig predictors of irregular menses at 1 yr FU:
| | | Wt. Min (kg) (SD) | | | Greater max.-min. wt diff (P = 0.003)
| | | 51.9 (6.9) | | | Current smoking (P = 0.01)
| | | Wt. Max (kg) (SD)
| | | 69.5 (10.8)
| | | Wt Max-min (kg) (SD)
| | | 17.6 (8.4)
| | | BN duration (mos) (SD)
| | | 65.5 (64.7)
| | | # Binges
| | | prior 2 wks (SD)
| | | 10.2 (10.6)
| | | # Purges prior 2 wks (SD)
| | | 11.7 (12.1)
| | | Hx of AN
| | | 20.7%
| | | Recency AN (mos) (SD)
| | | 18.5 (7.9)
| | | PreTreatment Maj. Dep:
| | | 22.0%
| | | PreTx smoker:
| | | 25.6%
| | | PreTx substance abuse:
| | | 23.2%
Authors, yr: | To assess rates and causes of death for a cohort of women with AN or BN and provide descriptive information on their ED and comorbid dx. | Inclusion: | Mean Age | Score: | Study Methods | Descriptive findings:
Herzog et al., 2000 | | Initially, meeting DSM III-R criteria for AN, AN/BN, or BN; Subsequently, using DSM IV definitions, met criteria for AN-R, ANBP, or BN. | NR | Fair | Data on mortality collected as part of a longitudinal study of AN and BN. Other data sources included death certificates, autopsy reports, relative interviews, and a National Death Index search. | AN
Design: | | Exclusion: | Sex: | Method of dx: | The Eating Disorders Longitudinal FU Evaluation (LIFE-EAT II) was administered to subjects at 6-mo intervals. General information regarding subjects' functioning in the mos prior to death was obtained by interviewing a family member. | At 11th yr FU: # of AN deaths: 7 (Crude mortality rate = 5.1%, 7 / 136) 3 subjects committed suicide.
Case series | | None | Female: 100% | SADS-L modified to include diagnostic criteria for DSM III-R as well as psychiatric hx, later updated to DSM IV criteria | | SMR indicates a sigly raised mortality rate for death at 9.6 times the expected rate (P = 0.001), 95% CI (3.86 – 19.8) and for suicide at 58.1times the expected rate (P = 0.001), 95% CI (11.7 – 169.7).
Comparison Group: | | Recruitment: | Race/ethnicity: | Funding: | | Characteristics of deceased participants:
No | | Between October 1987 andJune 1990, tx seekers at Massachusetts General Hospital. 556 recruited. | NR | NIMH ROI Grant, sponsor: Rubenstein Foundation and Harvard Eating Disorders Center. | | - At intake, 5 met ANBP dx: 2 met full AN and BN criteria; 2 met full AN criteria with BN sx; 1 met full BN criteria with AN sx.; - Ages: 24–46 yrs.; - Yrs ill at death: 9–28; - 2 met ANR criteria at intake, but later exhibited BN sx; - At time of death, of the 5 ANBP participants, 2 were classified as ANBP, 2 met AN-partial recovery criteria, 1 met AN-full recovery criteria.; - All had a hx of comorbid Axis I disorders: most common dx was alcoholism. Other comorbid disorders included bipolar disorder major depressive disorder and drug abuse.; - All participated in multiple types of tx: both individual psychotherapy and pharmacotherapy; - Hospitalized at least once: N = 6; - Participated in group therapy: N = 6; - Nutritional counseling: N = 5; - Participated in family therapy: N = 4; - All 3 subjects who committed suicide had reported suicidal ideation and 2 subjects had made at least one prior suicide attempt.
Location: | | Sample Size: | Mean duration of illness: | | | BN
Boston, MA, USA | | Using DSM IV criteria, participants classified as | 7.2 yrs | | | At 11th yr FU, # of BN deaths: 0
Yrs followed: 11 | | AN-R (N = 51),
| | ANBP (N = 85), and
| | BN (N = 110) status
| | Reasons for loss to FU:
| | NR
Author, Yr: | To assess factors associated with recovery and relapse in AN and BN | Inclusion: | Mean age at tx intake (SD): | Score: | Study Methods: | AN Findings
Herzog et al., 1999 | | DSM III-R for AN and BN at tx intake (Participants reclassified according to DSM IV criteria during the study); anorexic and bulimic episodes not separated by a period of remission of at least 8 wks duration. | ANR: 23.9 (8.5) | Good | FU interviews generally conducted by telephone by trained interviewers. Instruments included: Eating Disorders Longitudinal Interval FU Evaluation (LIFE-EAT-II)-semi-structured. | Descriptive Results
Design: | | Exclusion: | ANBP: 24.5 (5.9) | Method of dx: | Statistical Methods: | Full recovery:
Case series | | None | BN: 25.5 (6.5) | Modified version of Schedule for Affective Disorders and Schizophrenia - Lifetime version | Survival analysis, proportional hazards (Cox) regression | 33.7%
Comparison Group: | | Recruitment: | Sex: | Funding: | Outcome Categories: | At 2 yrs: ANR: 8%; ANBP: 13%
No | | Women who sought tx in eating disorder programs in Boston, MA between 1987 and 1990. An additional 21 women with AN recruited in 1991. | Female: 100% | NIMH, Rubenstein Foundation, Harvard Eating Disorders Center | Full recovery (absence of symptoms or presence of only residual symptoms for at least 8 consecutive wks) at some point over 90 mos | At 7 yrs: ANR: 34%; ANBP: 32%
Location: | | Sample size | Race/ethnicity: | | Partial recovery (reduction of symptoms to < full recovery for ≥ 8 consecutive wks | Partial recovery:
Boston, MA, USA | | Initial sample size: | NR | | | 83.7%
Yrs followed: | | ANR: 51 | Age at ED onset (SD): | | | At 2 yrs: ANR: 61%; ANBP: 67%
Median = 7.5; interviews conducted every 6 mos for 11 yrs | | ANBP: 85 | ANR: 17.5 (6.1) | | | At 7 yrs: ANR: 83%; ANBP: 82%
| | BN: 110 | ANBP: 16.9 (4.7) | | | Median time to partial recovery (wks):
| | Reasons for loss to FU: | BN: 19.4 (5.8) | | | ANR: 78; ANBP: 53
| | Dropouts: 17 | Proportion ABW: | | | Diff ANR and ANBP (P = NS)
| | Died (dx group and reasons NR): 7 | ANR: 0.73 (0.09) | | | Relapse after full recovery:
| | Analysis sample size: | ANBP: 0.82 (0.10) | | | 40%
| | NR | BN: 1.03 (0.15) | | | No remission through yr 7:
| | | Lifetime hx major depression: | | | ANR: 17%
| | | ANR: 64.7% | | | ANBP: 18%
| | | ANBP: 71.3% | | | Multivariate Results
| | | BN: 60.7% | | | Sig predictors of time to full recovery (adjusted):
| | | Lifetime hx Axis I: | | | Percent of ABW at intake: HM = 250.1, 95% CI (6.90–9.066) heavier is better
| | | ANR: 62.7% | | | Duration of intake episode: HM = 0.89, 95% CI (0.81–0.96), shorter is better
| | | ANBP: 78.1% | | | Sig predictors of time to partial recovery (adjusted):
| | | BN: 74.1% | | | Duration of intake episode: HM = 0.63, 95% CI (0.45–0.87) Shorter is better
| | | Lifetime hx Axis II: | | | Percent ABW at intake: HM = 18.89, 95% CI (0.32–1.105) Higher is better
| | | ANR: 25.5% | | | Hx of hospitalization: HM = 29.60, 95% CI (1.11–791.21) Fewer hospitalizations is better
| | | ANBP: 37.9% | | | Hx of major depression: HM = 1.64, 95% CI (1.07–2.51) Not having major depression is better
| | | BN: 23.2% | | | Duration of intake episode × proportion ABW: HM = 1.65, 95% CI (1.10–2.47); ABW values >93% and shorter intake episode is better than ABW < 93% and longer duration of intake episode
| | | Lifetime hx substance use disorder: | | | Percent ABW × hx of hospitalization: HM = 0.007, 95% CI (0.0001–0.44); ABW values ≤ 69% and having hx of hospitalization is better than ABW > 69% and no hx of hospiatlization
| | | ANR: 5.9% | | | BN Findings
| | | ANBP: 16.1% | | | Descriptive Results
| | | BN: 12.3% | | | Full recovery:
| | | Duration intake episode: | | | 73.8%
| | | ANR: 6.4 (6.7) | | | At 2 yrs: BN: 53%
| | | ANBP: 7.6 (5.4) | | | At 7 yrs: BN 73%
| | | BN: 6.1 (6.3) | | | Partial recovery:
| | | | | | 99.00%
| | | | | | At 2 yrs: BN: 88%
| | | | | | At 7 yrs: BN: 98%
| | | | | | Median time to partial recovery (wks): BN: 14
| | | | | | Relapse after full recovery:
| | | | | | 35.3%
| | | | | | Multivariate Results
| | | | | | Sig predictors of time to full recovery: none identified
| | | | | | Sig predictors of time to partial recovery: none identified
Authors, yr: | To assess the rates of recovery for restrictor and bulimic anorexics to determine whether bulimic behavior sig affects the course of AN. To assess possible subtypes of BN based on the presence or absence of a hx of AN. | Inclusion: | Age, mean (SD) (range), yrs | Score: | Study Methods | Descriptive Results
Herzog et al., 1996 | | DSM III-R criteria for BN and or AN | 24.5 (6.7) | Good | FU interviews conducted every 3 mos. Anniversary (12, 24, 36 mo) FUs conducted in person whenever possible. | % at least partially recovered:
Design: | | Exclusion: | ANR: 21 (18 – 27) | Method of dx: | Full recovery: asymptomatic (Psychiatric Status Rating PSR < 3) for at least 8 consecutive wks. | BN: 91%
Case series | | NR | ANBP: 22 (19 – 25) | Semi-structured interview (Schedule for Affective Disorders and Schizophrenia-Lifetime Version modified to include diagnostic criteria for DSM III-R eating disorders derived from the Diagnostic Interview Schedule). | Partial recovery: maintaining for at least 8 consecutive wks a PSR level of 3 or 4. Do not meet full criteria for AN or BN but still experience sig symptomatology. | Trend (P < 0.01)
Comparison Group: | | Recruitment: | BNSAN: 25 (21 – 29) | Eating Disorders Longitudinal FU Evaluation. | Analytic Strategy | % fully recovered:
No | | Participants who sought evaluation for an eating disorder at the Massachusetts General Hospital Eating Disorders Unit and at other Boston-area eating disorders programs between 10/87 and 6/90. | BNPAN: 23 (20 – 27) | Funding: | Fisher's Exact Test and Wilcoxon Rank Sum Test | BN: 62%
Location: | | Sample Size: | BN: 24 (20 – 30) | NIMH, Rubenstein Foundation, Eli Lilly and Co, The Boston Obesity, Nutrition Research Center | Kaplan-Meier survival method for probability of recovery. | Trend (P < 0.01)
Boston, MA | | Initial sample: | Diff between groups | | Cox proportional hazards models to identify prognostic factors | Multivariate Results
Yrs followed: 4 | | Telephone Screen: N = 554 | (P = NS) | | | BN Predictors of recovery; Adjusted for duration of the current episode (N = 150):
| | Met criteria: N = 268 | Sex: | | | Duration of current episode (P = NS)
| | Participated: N = 229 | Female: 100% | | | Age at onset of eating disorder (P = NS)
| | Dropout: N = 4 | Race/ethnicity: | | | Age at onset of first eating disorder (P = NS)
| | Analysis Sample: | NR | | | Current disorders involving a lack of impulse control
| | N = 225 | Age at onset of first disorder, mean (range), yrs | | | (P = NS)
| | ANR (AN and no regular bingeing or purging): N = 39 | ANR: 17 (15 – 20) | | | Wt < 90% of ideal (P = NS)
| | ANBP (AN and regularly engage in bingeing or purging): N = 37 | ANBP: 17 (15– 19) | | | Bingeing frequency (P = NS)
| | BNPAN (BN now and hx of AN): N = 28 | BNSAN: 17 (14 – 19) | | | Purging frequency (P = NS)
| | BNSAN (BN now, underwt at intake and do not meet full criteria for AN): N = 36 | BNPAN: 16 (15 – 18) | | | Current depression (P = NS)
| | BN (BN with no prior hx of AN): N = 89 | BN: 18 (16 – 20) | | | Personality disorder (P = NS)
| | | Diff between groups | | | Any current Axis I disorder (P = NS)
| | | (P = NS) | | | AN Predictors of recovery: Adjusted for duration of the current episode (N = 75):
| | | % attempted suicide: | | | Duration of current episode: RR = 0.50,
| | | ANR: 18 | | | 95% CI (0.27 – 0.94)
| | | ANBP: 33 | | | Age at onset of eating disorder (P = NS)
| | | BNSAN: 53 | | | Age at onset of first eating disorder (P = NS)
| | | BNPAN: 19 | | | Current disorders involving a lack of impulse control:
| | | BN: 28 | | | (P = NS)
| | | Diff between groups BNSAN had higher rates of suicide attempts versus BN and BNPAN | | | Bulimic behaviors (P = NS)
| | | (P < 0.001). | | | Current depression (P = NS)
| | | | | | Any current Axis I disorder (P = NS)
Author, yr | To asses the course and outcome of BN at 1 yr in a large cohort of women with ED. | Inclusion: | Mean Age At Intake, mean (SD): | Score: | Study Methods | Descriptive Results
Herzog et al., 1993 | | DSM III-R dx of AN and/or BN; Female; age ≥ 12; residence within 200 mi of Boston; English speaking; no evidence of organic brain syndrome or terminal illness. | 22.8 (7.4) | Good | Inperson FU interviews conducted every 3 mo after intake into the study. | Rate of recovery at 1 yr FU:
Design: | | Exclusion: | Age when first met criteria, mean (SD): | Method of dx: | Axis II: Structured Interview for DSM III Personality Disorders (SIDP). | First shift to subclinical (loss of full criteria without considering duration), N (%): 83 (86%)
Prospective cohort | | None | 18.8 (4.0) | Schedule for Affective Disorders and Schizophrenia - Lifetime Version (SADS-L), modified to include dx criteria for DSM III-R eating disorders. | FU: Eating Disorders Longitudinal Interval FU Evaluations (LIFE Eat II) | Partial recovery, N (%): 68 (71%)
Comparison Group: | | Recruitment: | Duration of episode, mos, mean (SD): | Funding: | For all disorders, Psychiatric Status Ratings (PSR) completed each FU point. Full recovery: at least 8 consecutive wks at a PSR level of 1 or 2; partial recovery: at least 8 consec wks at PSR level 3 or 4 or less than 8 consec wks at a PSR of 1 or 2. | Full recovery, N (%): 53 (56%)
No | | Patients who sought tx between 10/1987 and 6/1990 at the Massachusetts General Hospital Eating Disorders Unit and other Boston area eating disorder programs. Tx not controlled at study intake. | 57.7 (62) | NIMH | Statistical Methods | Predictors of partial recovery
Setting: | | 554 telephone screened | IBW at intake, %, mean (SD): | | Kaplan-Meier survival method for cumulative probability of recovery. | IBW:
Boston, MA, USA | | 268 (48%) met criteria for AN/BN | 104% (15%) | | Log rank to compare times to recovery across three dx. | Hazard multiplier: 1.07
Yrs followed: | | 229 (85%) agreed to participate | Comorbid Axis I dx, %: | | Cox regression to determine if intake psychopathology or eating disorder characteristics predicted time to recovery. | 95% CI (0.97 – 1.18)
1 yr (with some having 2 yr FU) | | Sample Size | 61% | | | Percent IBW did not predict time to recovery.
| | Initial sample: | In tx at 12-mo FU, %:
| | AN: N = 41 | 79%
| | BN: N = 98 | Sex:
| | Analysis sample size: | Female: 100%
| | Final N for 1 yr FU = 225 | Race/ethnicity:
| | AN = 41 | NR
| | BN = 96 | Intake duration, mean (SD):
| | AN/BN = 88 | 79 (73) mos range: 3 mos - > 10 yrs.
| | Completed 18 mo: 79%
| | Completed 24 mos: 45%
| | Only BN results presented in ET due to sample size and disease definition restrictions.
Authors, yr: | To investigate the long-term social adjustment of women with BN after tx and the course of sx and related dimensions over time. | Inclusion: | At FU: | Score: | Study Methods: | Descriptive Results:
Jäger et al., 2004 | | Women | Mean Age (SD): | Fair | Patients were followed up 8 yrs after tx completion. FU patients were interviewed by telephone and completed a mailed questionnaire. | Social adaptation: BN study sample vs general population
Design: | | DSM III-R for BN | 31.7 (4.1) yrs | Method of dx: | Telephone interview covering symptomatology and general health. | Married: 29.9% vs 61.4% (P < 0.001)
Case series | | Exclusion: | Sex: | DSM III-R, method not reported | Mailed questionnaire including: | Living with partner: 56.4% vs 73.4% (P < 0.001)
Comparison Group: | | Acute drug abuse | Female 100% | Funding: | Depression scale | Proportion of hospitalized patients/yr due to all reasons: 21.9% vs 10.7% (P < 0.001)
No | | Acute psychosis | | Robert-Bosch-Foundation, Stuttgart, Germany for 5 yrs and Lilly-Pharma, Germany for final assessment | An inventory of bodily complaints | No diff between BN and general pop. on employment, receive unemploy. benefits, welfare as main income source.
Location: | | Recruitment: | | | Freiburg Personality Inventory | Mental Health outcomes:
Hanover, Germany | | Continuation of Hanover BN study with add FU 8 yrs after start of tx. Initially 92 women offered systemic outpatient or analytic inpatient tx at Department of Psychosomatics and Psychotherapy, Hanover Medical School. | | | Eating Attitude Inventory | Comorbid clinical neurotic or psychosomatic dx in addition to BN reduced from 35 at intake to 8 at FU.
Yrs followed: 8.1 (0.6) | | Sample Size: | | | Eating Disorders Inventory | Personality disorders reduced from 13 at intake to 3 at FU.
| | Initial sample: | | | Bulimia Severity Score | Eating related outcomes
| | Patients in tx sample (N = 83) | | | Collateral info obtained by family and friends (no method reported) | Number binges per wk:62.5%
| | Reasons for loss to FU: | | | Statistical Method: | Still DSM III-R for BN: 28.9%
| | Refused (N = 3) | | | Chi^2^ and binomial tests | EDNOS (bulimic): 8.8%
| | Analysis sample: | | | Repeated measure ANOVA | EDNOS (anorexic): 1.3%
| | Participated through FU | | | Huynh-Feld-Epsilon correction | No DSM III-R ED dx: 61.2%
| | (N = 80) | | | Friedman ANOVA or Cochran Q test | Change over time (Discharge through 8 yr FU)
| | | | | 0.9% of missing values substituted by mean of adjacent measures | Binges decreased over time to FU in both tx groups (P < 0.001)
| | | | | Outcomes | Severity index decreased over time to FU in both tx groups (P < 0.001) Analytic inpatients better improvement over time (P < 0.007)
| | | | | Interview screen of ED symptoms and general health | Number normal meals per wk increased over time to FU (P < 0.001)
| | | | | Depression scale | Number restrictions of intake decreased over time to FU (P < 0.001)
| | | | | An inventory of bodily complaints | Analytic inpatients fewer restrictions (P = 0.048)
| | | | | Freiburg Personality Inventory | EAT-Bulimia decreased over time to FU (P < 0.001)
| | | | | Eating Attitude Inventory | Analytic inpatients having greater decrease (P = 0.005)
| | | | | Eating Disorders Inventory | EAT-Dieting decreased over time to FU (P < 0.001)
| | | | | Bulimia Severity Score | EDI-Ineffectiveness decreased over time to FU (P < 0.001)
| | | | | Calculated total score of intake restrictions | Depressiveness decreased over time to FU (P < 0.001)
| | | | | | Analytic inpatients having greater decrease (P = 0.036)
Authors, yr: | To compare bulimics with and without Borderline Personality Disorder at 1 yr FU after initiation of tx. | Inclusion: | Mean Age: | Score: | Study Methods | Family Hx of psychiatric illness:
Johnson, Tobin, and Dennis, 1990 | | DSM III-R criteria for BN | 25 (5.1); Mode: 15 yrs; diff between groups (P = NS) | Poor | FU assessments were conducted by mail 1 yr after entry into tx. | Borderline: 76%
Design: | | Exclusion: | Sex: | Method of dx: | Tx intervention: Combination of CBT and psychodynamic; frequency: 1 – 2X per wk (depending on patient) for some portion of the yr. | Nonborderline: 32%
Case series | | NR | Female: 100% | Diagnostic Survey of Eating Disorders, revised; Borderline Syndrome Index (BSI): Borderline group: ≥ 23; Nonborderline group: ≤ 12 | Analytic Strategy | Diff between groups (P < 0.01)
Comparison Group: | | Recruitment: | Race/ethnicity: | Funding: | Chi-square comparisons | Family hx of affective disorder:
No | | Patients who sought tx at University of Chicago Medical Center | Mode: Caucasian | Barr and Dunagan Foundation | Outcomes: | Borderline:48%
Location: | | Sample Size: | Age of onset of bingeing: | | Remission: no episodes of binge eating or purging during two wks prior to FU | Nonborderline: 32%
University of Chicago, IL, USA | | N = 55 | 16.7 | | Sigly improved: Reduced frequency of binge/purge by 50% from initial assessment to 1 yr FU. | Diff between groups (P = NS)
Yrs followed: 1 | | BPD: N = 21 | Diff between groups (P = NS) | | | Family hx of alcoholism:
| | NBPD: | Duration of binge eating behavior, mean yrs: | | | Borderline:48%
| | N = 19 | 6.8 | | | Nonborderline:16%
| | | Diff between groups (P = NS) | | | (P = NR)
| | | Age of onset of vomiting: | | | Continued to meet DSM III-R criteria for BN:
| | | 19.1 | | | Borderline: 62%
| | | Diff between groups (P = NS) | | | Nonborderline: 21%
| | | Duration of vomiting, mean yrs: | | | Diff between groups (P < 0.05); Borderline did worse.
| | | 5.6 | | | Complete remission:
| | | Diff between groups (P = NS) | | | Borderline: 10%
| | | Number of dieting attempts during last yr, mean: | | | Nonborderline: 47%
| | | 20 | | | Sigly improved:
| | | Diff between groups (P = NS) | | | Borderline: 48%
| | | Controlled dieting behavior: | | | Nonborderline: 42%
| | | Diff between groups (P < 0.05) | | | Unimproved:
| | | NBPD engaged in more controlled dieting | | | Borderline: 24%
| | | Current wt, mean (lbs): | | | Nonborderline: 5%
| | | 127 | | | Increase in symptoms:
| | | Diff between groups (P = NS) | | | Borderline: 19%
| | | Previous low wt, mean (lbs): | | | Nonborderline: 5%
| | | 113 | | | BDI, mean:
| | | Diff between groups (P = NS) | | | Borderline: 18
| | | Previous high wt, mean (lbs): | | | Nonborderline: 4
| | | 146 | | | (P = NR)
| | | Diff between groups (P = NS) | | | GSI/SCL-90:
| | | Frequency of binges per wk: | | | Borderline: 1.24
| | | 10 | | | Nonborderline: 0.34
| | | Diff between groups (P = NS) | | | (P = NR)
| | | Binge days per wk: | | | In tx at end of 1 yr, N:
| | | 5 | | | Borderline: 14
| | | Diff between groups (P = NS) | | | Nonborderline: 7
| | | Frequency of purging per wk: | | | Diff between groups (P < 0.05)
| | | 13 | | | Mean number of tx sessions:
| | | Diff between groups (P = NS) | | | Borderline: 67
| | | Purge days per wk: | | | Nonborderline: 35
| | | 5 | | | Diff between groups (P < 0.05)
| | | Diff between groups (P = NS)
| | | BDI:
| | | Borderline: 27
| | | Nonborderline: 9
| | | Diff between groups (P < 0.001)
| | | Borderline more depressed
| | | Global Severity Index of SCL-90:
| | | Borderline: 1.93
| | | Nonborderline: 0.69
| | | Diff between groups (P < 0.001)
| | | Borderline greater severity
| | | Drive for thinness:
| | | Diff between groups (P < 0.01)
| | | Borderline worse
| | | Distorted body image:
| | | Diff between groups (P < 0.01)
| | | Borderline worse
Authors, yr: | To determine mortality ratios and predictors of fatal outcome in women dx with AN or BN. | Inclusion: | Mean Age | Score: | Study Methods | Descriptive
Keel et al., 2003 | | (1) DSM III-R dx of AN or BN retrospectively (2) female (3) min age of 12 yrs (4) residence within 200 miles of Boston (5) English speaking, and (6) no evidence of organic brain syndrome or terminal illness. | NR | Fair | During FU interviews, the Longitudinal Interval FU Evaluation adapted for EDs used to assess ED and comorbid psychiatric disorders. Course of disorder coded on a wk-by-wk basis using PSR. Social adjustment evaluated on a 5-point scale. GAF used to evaluate overall level of symptom severity from all disorders and psychosocial function. Social adjustment, GAF scores, and tx rated on a wk-by-wk basis throughout FU. Interviews conducted, in person when possible, every 6 to 12 mos. | Number of Deaths:
Design: | | Exclusion: | Sex: | Method of dx: | FU telephone calls conducted to determine vital status for all longitudinal study participants as of October 2000 | 11 (4.5%)
Case series | | None | Female: 100% | Structured diagnostic interview | Statistical Methods | AN:10
Comparison Group: | | Recruitment: | Race/ethnicity: | Funding: | Crude mortality rates and SMRs calculated. Expected number of deaths derived from US decennial life tables for 1989-1991. Expected number of suicides derived from 1995 Annual Report: VitalStatistics of Massachusetts. | ANR: 5
No | | 294 women recruited for participation in a prospective longitudinal study between January 1, 1987, and December 31, 1991. Virtually all seeking outpatient tx for their Ed at the Massachusetts General Hospital Eating Disorders Unit or other Boston area eating disorder programs (37% received inpatient). | NR | NIMH; Eli Lily and Co.; Rubenstein Foundation; Harvard Eating Disorders Center | Cox regression models used to determine predictors of fatal outcome. Multivariate regression model used to predict death. | ANBP: 5
Location: | | Sample Size: | | | | Diff by subtype (P = NS)
Boston, Mass | | N = 294 met study criteria | | | | BN: 1
Yrs followed: | | N = 250 agreed to participate | | | | Crude mortality:
Mean: 8.6 | | N = 246 randomized and participated (4 dropped out after intake interview) | | | | AN: 7.4%
Median: 9 | | Retrospectively application of DSM IV criteria: | | | | BN: 0.9%
| | Met AN criteria: N = 136 | | | | SMR
| | Met BN criteria: N = 110 | | | | AN: 11.6; 95% CI (5.5–21.3)
| | | | | | BN: 1.3; 95% CI (0.0–7.2)
| | | | | | Mortality rates elevated in AN but not BN
| | | | | | Cause of death
| | | | | | ANBP: Pneumonia
| | | | | | ANR (N = 3) Suicide
| | | | | | ANBP: Cardiac dysrythmia
| | | | | | ANBP: Alcohol poisoning
| | | | | | ANBP: Diabetes mellitus
| | | | | | BN: Mitral valve prolapse
| | | | | | ANR: Amyotrophic lateral sclerosis
| | | | | | ANBP: Suicide
| | | | | | ANR: Heart and liver failure
| | | | | | SMR associated with suicide for AN: 56.9, 95% CI (15.3–145.7), sig higher
| | | | | | Multivariate Results
| | | | | | Sig predictors of death among AN patients (controlling for age and duration of illness before intake):
| | | | | | Greater severity of alcohol use disorders (P < 0.001)
| | | | | | Greater severity of substance use disorders (P = 0.03)
| | | | | | Worse social adjustment (P = 0.02)
| | | | | | Worse GAF scores at FU (P = 0.01)
| | | | | | Using the Bonferroni-corrected P = 0.0016, only severity of alcohol use disorder remained sig.
| | | | | | Predictors of time to death among AN patients
| | | | | | Duration of illness at tx intake: HM = 1.48, 95% CI (1.11–1.99) (P = 0.001)
| | | | | | Affective disorder hospitalization at intake: HM = 0.0001,
| | | | | | 95% CI (0.00–0.27) (P = 0.001)
| | | | | | Suicidality associated with mental illness other than ED and substance abuse: HM = 23.92, 95% CI (0.81–705.52) (P = 0.05)
| | | | | | Severity of alcohol use over course of illness: HM = 5.55,
| | | | | | 95% CI (1.68–18.29) (P = 0.001)
Authors, yr: | To determine the independence of the association between body dissatisfaction and depression from bulimic symptoms among women who had BN at the time of the baseline assessment. | Inclusion: | Mean Age (SD): | Score: | Study Methods: | Multivariate Findings:
Keel et al., 2001 | | Met DSM III criteria for BN, with the add criterion of binge eating coupled with purging episodes occurring at least 3 times per wk for at least 6 mos prior to study participation. Additional inclusion and exclusion criteria reported in the original study (Mitchell et al., 1990). | 34.3 (5.2) | Fair | Participants were mailed consent forms and questionnaires to complete at home, and asked to complete an interview either over the telephone or in person. Face-to-face interviews were conducted either at the University of Minnesota's Eating Disorders research office or within subjects' homes. | Regression of body dissatisfaction on bulimic symptoms and depression:
Design: | | Exclusion: | Sex: | Method of dx: | Participants were administered the HDRS (depression), EDI (ED symptoms), SCID-I, and BDQ (body dissatisfaction) at baseline and FU. | Baseline concurrent body dissatisfaction (N = 101) (R2 = 0.21)
Case Series | | One woman removed from analyses because baseline and FU assessments indicated she had never met full DSM IV criteria for BN because her binge eating episodes were not objectively large. | Female: 100% | NR | Analytic Strategy: | Bulimic symptoms β (SEB), β: 0.59 (0.15), 0.36 (P < 0.001)
Comparison Group: | | Recruitment: | Race/ethnicity: | Funding: | Multiple regression analyses utilized to test the independence and strength of concurrent and prospective associations of body dissatisfaction, depression, and BN symptoms. | Depression, β (SE B), β: 0.22 (0.11), 0.19 (P < 0.05)
No | | Women with BN who completed participation in a controlled tx outcome study at the U of Minnesota's ED Research offices, Minneapolis, MN between 1985 and 1987 (Mitchell et al., 1990) were mailed an invitation to participate in FU study. | Caucasian: N = 100, 99% | McKnight Center Grant; NIH Obesity Grant | | FU concurrent body dissatisfaction (N = 97) (R2 = 0.32)
Location: | | Sample Size: | Non-Caucasian N = 1, 1% | | | Bulimic symptoms, β (SE β), β: -7.32 (1.73), -0.37 (P < 0.001)
USA | | Original sample | Education: | | | Depression, β (SE β), β: 1.92 (0.49), 0.35 (P < 0.001)
Yrs followed (SD): | | Recruited: N = 125 | Not completed HS: 1% | | | Prospective (N = 97) (R2 = 0.19)
10 (0.7) | | Reasons for loss to FU: | 4-yr college: 42% | | | Bulimic symptoms, β (SE β), β -1.22 (0.76), -0.17 (P = NS)
| | Located: N = 115 (92%) | Graduate school: 15% | | | Depression, β (SE β), β 1.26 (0.54),0.24 (P < 0.5)
| | Exclusion due to not meeting DSM IV criteria: N = 1 | Occupational level: | | | Baseline body dissatisfaction, β (SE β), β: 1.54 (0.47), 0.35 (P < 0.01)
| | Reasons NR: N = 13 | Administrative: 37% | | | Regression analyses for depression and body dissatisfaction
| | Analysis sample: | Clerical/sales: 29% | | | Baseline concurrent (N = 101) (R@ = 0.09), β = 0.33 (P < 0.01)
| | N = 101 | with approximately 10% | | | Depression on Body Dissatisfaction, β (SE β): 0.27 (0.08)
| | | Manual position: 11% | | | Body dissatisfaction on Depression, β (SE β): 0.35 (0.11)
| | | Professional position: 10% | | | FU concurrent ((P < 0.001)
| | | | | | Depression on Body Dissatisfaction, β (SE β): 0.08 (0.02)
| | | | | | Body dissatisfaction on Depression, β SE β: 2.45 (0.51)
| | | | | | Prospective - baseline to FU (N = 97)
| | | | | | Depression on Body Dissatisfaction (controlling for baseline depression, R^2,^ = 0.08 SE(P = NS)
| | | | | | Body dissatisfaction on Depression (controlling for baseline body dissatisfaction), R2 = 0.016, β (SE β) β: 1.04 (0.52), 0.20 (P < 0.05)
Authors, yr: | To compare definitions of ED outcome found in the BN literature and to determine the impact of definitions on the description and prediction of outcome. | Inclusion: | Mean Age | Score: | Study methods | Descriptive Results:
Keel, Mitchell, Davis et al., 2000 | | Met the DSM III criteria for BN and the additional criterion of binge eating coupled with vomiting or laxative abuse at least 3 times each wk for 6 mos preceding presentation | 35.3 (5.1) yrs | Fair | Definitions of outcome used in different studies involving a FU duration of at least 5 yrs compared. Diffs examined at 10 yr FU. | Full recovery ranged across defs from 47% to 38% in this sample
Companion article: | | Exclusion: | Sex: | Method of dx: | Defs of outcome varied in 3 ways: | in a linear relationship with required duration of abstinence (P = 0.01).
Keel et al., 1999 | | None | Female: 100% | DSM IV SCID-I/P for Axis I disorders + addendum for impulse control disorders at FU. | - Duration of abstinence required for full remission or full recovery. Required abstinence varied from 2 -12 mos across studies, with modal duration of 2 mos.; - Number of categories into which outcome is placed varies from 2–4 classifications.; - How ED outcome categories prior to performing statistical analyses combined. | For every add mo of abstinence required for full recovery, approx 1% of women reclassified from fully to partially remitted. Diffs in def affected description of outcome for 9% of the sample (N = 16).
Keel, Mitchell, Miller et al., 2000 | | Recruitment: | Race/ethnicity: | Funding: | Outcome measures: | At the trend level, a lifetime hx of substance use disorders was consistently associated with ED outcome (P < 0.10). There were no other consistent prognostic variables across studies.
Design: | | Participation in two previous studies on BN (Mitchell, Pyle et al., 1988, and Mitchell, Pyle et al., 1990) who were initially evaluated at the University of Minnesota's Eating Disorders Clinic between 1981-1987.Subjects from 2 previous studies recontacted via letter from one of investigators. | White: 99%, N = 171 | McKnight Center Grant for Eating Disorders Research, NIH Obesity Center; NIMH; American Psychological Association; Minnesota Women Psychologists' Association, University of Minnesota. | 1.Hsu and Sobkiewicz (1989): Full recovery (no binge eating or purging over previous six mos) | Associations between other outcomes variables and ED outcomes across definitions of ED outcome:
Case Series | | Final participation rate = 80.5% | Not White: 1%, N = 2 | | 2. Fallon et al. (1991): Full recovery (Psychiatric Status Rating < 3 for 8 consecutive wks) | Depression:
Comparison Group: | | No diff in participation rates between the 2 studies | Mean duration of FU, yrs (SD): | | 3. Collings and King (1994): Full recovery (no symptoms during 12 mos preceding assessment | 1. (P = 0.04) 2. (P < 0.001) 3. (P = 0.05)
No | | Sample Size: | 11.5 (1.9) | | 4. Fairburn et al. (1995): No ED or EDNOS of clinical severity that does not meet criteria for AN or BN | 4. (P = 0.003) 5. (P < 0.001) 6. (P = 0.02)
Location: | | Original (N = 222) | Education: | | 5. Reiss and Johnson-Sabine et al. (1995): Good outcome (not bingeing and/or vomiting/ purging at all or doing so < 1x/mo)/ Keel et al. (1999): Full remission - narrow (no binge eating or purging over previous 6 mos and wt and shape cannot unduly influence self-evaluation), broad (Psychiatric Status Rating < 3 over 8 consecutive wks); partial remission (less remitted than full remission but more remitted than EDNOS)/ Abraham (1998): Recovered (did not meet DSM IV criteria for AN, BN, or EDNOS) | Affective:
USA | | Reasons for loss to FU: | HS: 99% | | 6. Herzog (1999): Full recovery (episode is over if psychiatric status rating is less than 5 for 8 consecutive wks (or less than 8 consecutive wks at psychiatric status rating < 3) | 1. (P = 0.09) 2. (P < 0.001) 3. (P = 0.02)
Yrs followed: | | Not located (confirmed not deceased) (N = 22) | College: 30% | | | 4. (P < 0.001) 5. (P < 0.001) 6. (P = 0.03)
Mean: 11.5 (1.9) | | Deceased (N = 1) | Graduate school:15% | | | Substance use:
| | Severely disabled and blind (N = 1) | Ever married: | | | 1. (P = 0.09) 2. (P < 0.001) 3. (P = 0.02)
| | Refused (N = 21) | 75% | | | 4. (P < 0.001) 5. (P < 0.001) 6. (P = 0.03)
| | Did not meet DSM IV criteria for BN based on initial assessment and SCID-I/P at FU (N = 4) | Still in 1st marriage: 50% | | | Current therapy:
| | Final sample (N = 173) | Vocation: | | | 1. (P = NS) 2. (P = NS) 3. (P = 0.008)
| | Analysis sample size: | Manual labor: < 10% | | | 4. (P = NS) 5. (P = 0.002) 6. (P = 0.04)
| | N = 173 | Clerical/sales: 26.6% | | | Current meds:
| | | Administration: 33.5% | | | 1. (P = 0.01) 2. (P < 0.001) 3. (P = NS)
| | | Professional: < 10% | | | 4. (P = 0.001) 5. (P = 0.002) 6. (P = 0.007)
| | | | | | Body mass index:
| | | | | | 1. (P = NS) 2. (P = NS) 3. (P = NS)
| | | | | | 4. (P = NS) 5. (P = NS) 6. (P = NS)
| | | | | | Body image:
| | | | | | 1. (P < 0.001) 2. (P < 0.001) 3. (P < 0.001)
| | | | | | 4. (P < 0.001) 5. (P < 0.001) 6. (P < 0.001)
| | | | | | Impulse control:
| | | | | | 1. (P = 0.02) 2. (P < 0.001) 3. (P = 0.02)
| | | | | | 4. (P = 0.01) 5. (P = 0.01) 6. (P = 0.01)
| | | | | | Social adjustment:
| | | | | | 1. (P < 0.001) 2. (P < 0.001) 3. (P < 0.001)
| | | | | | 4. (P = 0.001) 5. (P < 0.001) 6. (P < 0.001)
| | | | | Measures: | Associations between prognostic variables and ED outcomes across definitions of outcome:
| | | | | - Hamilton Depression Rating Scale; - Structured Clinical Interview for the DSM IV Axis I Disorders; - Body Shape Questionnaire; - SAS-SR; - Control Scale of the Multidimensional Personality Questionnaire (MPQ-8); - Eating Disorders Questionnaire | Depression:
| | | | | Analytic Strategy: | 1. (P = NS) 2. (P = NS) 3. (P = NS)
| | | | | All analyses performed with all available data. The specific analytic strategies utilized not reported. | 4. (P = NS) 5. (P = NS) 6. (P = NS)
| | | | | | Affective disorder:
| | | | | | 1. (P = 0.007) 2. (P = NS) 3. (P = 0.002)
| | | | | | 4. (P = NS) 5. (P = NS) 6. (P = 0.05)
| | | | | | Substance use:
| | | | | | 1. (P = NS) 2. (P = 0.004) 3. (P = 0.04)
| | | | | | 4. (P = 0.005) 5. (P = 0.01) 6. (P = NS)
| | | | | | Hx of AN:
| | | | | | 1. (P = NS) 2. (P = NS) 3. (P = NS)
| | | | | | 4. (P = NS) 5. (P = NS) 6. (P = NS)
| | | | | | Personality disorder:
| | | | | | 1. (P = NS) 2. (P = NS) 3. (P = NS)
| | | | | | 4. (P = NS) 5. (P = NS) 6. (P = NS)
| | | | | | Tx:
| | | | | | 1. (P = NS) 2. (P = NS) 3. (P = NS)
| | | | | | 4. (P = NS) 5. (P = NS) 6. (P = NS)
| | | | | | Age of onset:
| | | | | | 1. (P = NS) 2. (P = 0.05) 3. (P = NS)
| | | | | | 4. (P = 0.027) 5. (P = NS) 6. (P = NS)
| | | | | | Age of present:
| | | | | | 1. (P = NS) 2. (P = NS) 3. (P = 0.001)
| | | | | | 4. (P = NS) 5. (P = NS) 6. (P = 0.009)
| | | | | | Severity of symptoms:
| | | | | | 1. (P = NS) 2. (P = NS) 3. (P = 0.02)
| | | | | | 4. (P = NS) 5. (P = NS) 6. (P = NS)
| | | | | | Duration of symptoms:
| | | | | | 1. (P = 0.004) 2. (P = NS) 3. (P = 0.01)
| | | | | | 4. (P = NS) 5. (P = NS) 6. (P = 0.009)
Authors, yr: | To determine and describe predictive factors of long-term outcome for females with BN | Inclusion:. | Mean Age | Score: | Study Methods | Descriptive Results:
Keel et al., 1999 | | At baseline, participants needed to meet DSM III criteria for BN and also needed to purge ≥; 3 times/wk during 6 mos prior to baseline evaluation; needed to meet criteria for past BN on SCID-I/P at FU evaluation. | 35.3 (5.1) yrs | Fair | Questionnaires sent by mail: | Outcome for total population:
Companion article: | | Exclusion: | Duration of FU: | Method of dx: | Eating Disorders Questionnaire, | AN: 1 (0.6%)
Keel, Mitchell, Miller et al., 2000 | | NR | 11.5 (1.9) | DSM IV SCID-I/P for Axis I disorders + addendum for impulse control disorders at FU. | Hamilton Depression Rating Scale, | BN: 19 (11%)
Keel, Mitchell, Davis et al., 2000 | | Recruitment: | Mean age at onset: | Funding: | Hamilton Anxiety Rating Scale, | BED: 1 (0.6%)
Design: | | Participation in two previous studies on BN (Mitchell, Pyle et al., 1988, and Mitchell, Pyle et al., 1990) who were initially evaluated at the University of Minnesota's Eating Disorders Clinic between 1981-1987.Subjects from 2 previous studies recontacted via letter from one of investigators. | 16.8 (2.5) | McKnight Center grant for Eating Disorders Research; Obesity Center grant P30 DK50456, NIH; research training grant, dissertation grants from APA and Minnesota Women Psychologists' Assoc., dissertation fellowshipfrom U of Minn | Multidimensional Personality Questionnaire Scale 8: Control/Impulsiveness, | EDNOS: 31 (17.9%)
Case series | | Final participation rate = 80.5% | Sex: | | Body Shape Questionnaire | By narrow def of remission
Comparison Group: | | No diff in participation rates between the 2 studies | Female: 100% | | Personal interview conducted either at the Eating Disorders Research Office or at home (54%), or over phone (46%). Structured interviews (DSM IV SCID-I/P) conducted by authors or trained research assistants. | Full remission: 72 (41.6%)
No | | Sample Size: | Race/ethnicity: | | Outcome definitions | Partial remission: 49 (28.3%)
Location: | | Original (N = 222) | White: 99% | | Full Remission: | By broad def of remission
USA | | Not located (confirmed not deceased) (N = 22) | Not White: 1% | | Narrow definition: freedom from disordered eating for at least 6 mos; wt and shape could not unduly influence how subject felt about or evaluated herself | Full remission: 81 (46.8%)
Yrs followed: | | Deceased (N = 1) | Education: | | Broad definition: absence from disordered eating for at least 8 wks with no restrictions based on influence of wt or shape on self-evaluation. | Partial remission: 40 (23.1%)
Mean duration of FU 11.5 (1.9) | | Severely disabled and blind | HS: 99% | | Partial remission: not meeting criteria for full remission and not meeting DSM IV criteria for any ED | Comparisons of wt variables measured at Baseline and FU:
| | (N = 1) | College: 30% | | Analytic Methods | Change in BMI:
| | Refused (N = 21) | Graduate sch: 15% | | Parametric and nonparametric tests used to assess diff in means and proportions. Due to large # of tests, sig level = a < 0.01 and family-wise error controlled with Dunn test corrections. | Baseline: 21.2 (2.7)
| | Did not meet DSM IV criteria for BN based on initial assessment and SCID-I/P at FU (N = 4) | Ever married: 75% | | Outcomes | FU: 22.1 (3.6)
| | Final sample (N = 173) | Still in 1^st^ marriage: 50% | | Measured both categorically (remission - full and partial - or not in remission) and continuously (log of the number of mos since last binge/purge episode) | (P < 0.001)
| | Analysis sample size: | Vocation: | | Duration of FU between 2 subsamples not different for categorical variables (P = 0.09), but sig different (P = 0.005) for continuous variables so continuous prognostic variables controlled for the variance explained by duration of FU. | Change in actual wt:
| | N = 173 but varies based on completion of scales. | Manual labor: < 10% | | Eating Disorder Outcome did not differ based on the narrow (P = NS) or full (P = NS) defs of remission or on # of mos since last ED symptom. | Baseline: 58.3 (8.5)
| | Scales had to be 80% complete for inclusion. | Clerical/sales: 26.6% | | | FU: 60.7 (10.9)
| | | Administration: 33.5% | | | (P < 0.01)
| | | Professional: | | | Change in desired wt:
| | | < 10% | | | Baseline: 53.1 (5.2)
| | | | | | FU: 56.5 (6.2)
| | | | | | (P < 0.001)
| | | | | | Change in highest wt:
| | | | | | Baseline: 66.38 (11.43)
| | | | | | FU, 69.79 (13.18)
| | | | | | (P < 0.001)
| | | | | | Change In lowest wt:
| | | | | | Baseline 50.91 (7.38)
| | | | | | FU: 50.91 (8.07) (P = NS)
| | | | | | Change in wt not clinically sig due to aging of the sample
| | | | | | Body Shape Questionnaire
| | | | | | FU: Mean score = 86.8 (36.7)
| | | | | | Compared to a community sample of 535 women: 81.5 (28.4) (P = NS)
| | | | | | Compared to cohort with BN: 136.9 (22.5) (P < 0.001)
| | | | | | Subjects with ED at FU had higher BSQ scores at FU (categorical)
| | | | | | (P < 0.001), continuous (P < 0.001)
| | | | | | Prognostic Factors for ED outcome (measured categorically and continuously):
| | | | | | Remission: N = 121
| | | | | | Disordered eating: N = 52
| | | | | | Outcome analysis measurement approach:
| | | | | | Cat: categorical
| | | | | | Con: continuous
| | | | | | Both: measured both ways
| | | | | | Age of onset:
| | | | | | 16.8 (2.5) yrs
| | | | | | Both (P = NS)
| | | | | | Duration of symptoms at baseline:
| | | | | | 5.9 (3.6) yrs
| | | | | | Both (P < 0.01)
| | | | | | Baseline severity of ED symptoms:
| | | | | | Both (P = NS)
| | | | | | AN prior to BN:
| | | | | | Cat (P = NS)
| | | | | | Lifetime Mood Disorder
| | | | | | Remission: 62.8%
| | | | | | Disordered eating: 71.2%
| | | | | | Both (P = NS)
| | | | | | Baseline Depression
| | | | | | Remission: 7.7%
| | | | | | Disordered eating: 8.0%
| | | | | | Both (P = NS)
| | | | | | Lifetime Anxiety Disorder
| | | | | | Remission: 29.8%
| | | | | | Disordered eating: 34.6%
| | | | | | Both (P = NS)
| | | | | | Baseline Anxiety Disorder
| | | | | | Remission: 4.6%
| | | | | | Disordered eating: 6.1%
| | | | | | Both (P = NS)
| | | | | | Lifetime Substance Use
| | | | | | Remission: 53.8%
| | | | | | Disordered eating: 74.0%
| | | | | | Cat (P < 0.05); Con (P < 0.01)
| | | | | | Baseline Substance Use
| | | | | | Remission: 19.2%
| | | | | | Disordered eating: 43.8%
| | | | | | Cat (P < 0.05); Con (P < 0.001)
| | | | | | Lifetime Impulse Control
| | | | | | Remission: 16.5%
| | | | | | Disordered eating: 21.2%
| | | | | | Both (P = NS)
| | | | | | Baseline Impulse Control
| | | | | | Remission: 46.3%
| | | | | | Disordered Eating: 58.1%
| | | | | | Both (P = NS)
| | | | | | Multidimensional Personality Questionnaire
| | | | | | Cross-sectional:
| | | | | | Cat (P < 0.01); Con (P < 0.05)
| | | | | | Treatment received in past
| | | | | | Took meds
| | | | | | Remission:
| | | | | | 69.4%
| | | | | | Disordered eating:
| | | | | | 82.7%
| | | | | | Cat (P = NS); Con (P < 0.05)
| | | | | | Therapy in past
| | | | | | Remission: 95%
| | | | | | Disordered eating: 94.2%
| | | | | | Both (P = NS)
Authors, yr: | To investigate the predictive validity of BN as a diagnostic category, using 10+ yr FU data in a sample of women with BN. | Inclusion: | Mean Age | Score: | Study Methods: | Descriptive:
Keel, Mitchell, Miller et al., 2000 | | Met the DSM III criteria for BN and the additional criterion of binge eating coupled with vomiting or laxative abuse at least 3 times each wk for 6 mos. | 35.3 (5.1) | Fair | Participants completed the SCID-I for DSM IV Axis I Disorders and the HRSD. | At FU, 19 (11.0%) met BN criteria
Companion article: | | Exclusion: | Sex: | Method of dx: | Outcomes: | 62 (35.8%) had a lifetime hx of AN
Keel et al., 1999 | | None | Female: 100% | DSM IV SCID-I/P for Axis I disorders + addendum for impulse control disorders at FU. | ED outcome was defined both as categorical and continuous variables. Categorical def: distinguished between those who met DSM IV criteria for an ED and those free from recurrent ED symptoms 1 mo prior to assessment. Continuous def: natural log of mos between most recent binge or purge episode and assessment. | 1 had current AN.
Keel, Mitchell, Davis et al., 2000 | | Recruitment: | Race/ethnicity: | Funding: | Analytic Strategy: | 19 (11.0% of total sample) had a lifetime hx of BED
Design: | | Participation in two previous studies on BN (Mitchell, Pyle et al., 1988, and Mitchell, Pyle et al., 1990) who were initially evaluated at the University of Minnesota's Eating Disorders Clinic between 1981-1987.Subjects from 2 previous studies recontacted via letter from one of investigators. | Caucasian (N = 176) 98.9% | McKnight Grant, Obesity Center grant from National Institute of Diabetes and Digestive and Kidney Diseases, NIMH grant, and dissertation grants from the American Psychological Association, the Minnesota Women Psychologists' Association, and the University of Minnesota | Chi Square and t-tests. Tests were two-tailed with an alpha of 0.01. | 1 had current BED.
Case Series | | Final participation rate = 80.5% | Non-caucasian (N = 1) 1% | | | 32 (18.5% of total sample) had current EDNOS. EDNOS was most common ED at FU (P < 0.001); Among these women, recurrent binge-purge episodes or purging alone were sig more common than recurrent binge eating alone (P = 0.01).
Comparison Group: | | No diff in participation rates between the 2 studies | Mean duration of FU, yrs (SD): | | | Relation of ED Outcome to Axis I Disorders at 10-Yr FU:
No | | Sample Size: | 11.5 (1.9) | | | ED measured as categorical variable (Remitted versus Present)
Location: | | Original (N = 222) | | | | Remitted: N = 121; Present: N = 52
USA | | Reasons for loss to FU: | | | | Mood Disorder:
Yrs followed: | | Not located (confirmed not deceased) (N = 22) | | | | Remitted: 2 (1.7%); Present: 11 (21.2%) (P < 0.001)
Mean duration of FU: 11.5 (1.9) | | Deceased (N = 1) | | | | Anxiety Disorder:
| | Severely disabled and blind (N = 1) | | | | Remitted: 20 (16.5%); Present: 6 (11.5%) (P = NS)
| | Refused (N = 21) | | | | Substance Disorder:
| | Did not meet DSM IV criteria for BN based on initial assessment and SCID-I/P at FU (N = 4) | | | | Remitted: 1 (0.08%); Present: 8 (15.4%) (P < 0.001)
| | Final sample (N = 173) | | | | Impulse Control Disorder:
| | Analysis sample size: | | | | Remitted: 2 (1.7%); Present: 9 (17.3%) (P < 0.001)
| | N = 173 | | | | Mood disorders and HDRS scale scores:
| | | | | | Data: NR (P = 0.002)
| | | | | | ED measured as continuous variable (natural log of mos between most recent binge/purge episode and assessment):
| | | | | | Mood Disorder:
| | | | | | Axis I Absent: 2.6 (2.0%); Axis I Present: 0.4 (1.3%) (P < 0.001)
| | | | | | Anxiety Disorder:
| | | | | | Axis I Absent: 2.3 (2.0%); Axis I Present: 2.9 (2.0%) (P = NS)
| | | | | | Substance Disorder:
| | | | | | Axis I Absent: 2.5 (2.0%); Axis I Present: 0.2 (0.5%) (P < 0.001)
| | | | | | Impulse Control Disorder:
| | | | | | Axis I Absent: 2.5 (2.0%); Axis I Present: 0.5 (1.3%) (P < 0.001)
| | | | | | Mood disorders and HDRS scale scores:
| | | | | | Data: NR (P = 0.01)
Authors, yr: | Calculate a standardized mortality rate for eating disorders in a large population | Inclusion: | Mean Age (yrs): | Score: | Study methods | Descriptive Results
Patton, 1988 | | Eating disorder dx | AN: 22.4 | Fair | Attempted to locate by: | Mortality rate
Design: | | AN (Russell, 1970): | BN: 23.5 | Method of dx: | Contact with referring physician | Crude mortality rate (%)
Case series | | Loss of 25% of BW | Mean Wt (kg): | Russell diagnostic criteria for AN and BN applied retrospectively to case note description of presentation | Last known address | AN: 3.1
Comparison Group: | | Amenorrhea | AN: 41 | Funding: | National Health Service Central Registry | BN: 3.3
No | | Fear of putting on wt | BN: 58.9 | Grant from the Wellcome Foundation | Located 95.6% | Expected mortality rate:
Location: | | BN (Russell, 1979): | Sex: | | FU conducted, 1985-86 | AN: 1.83
United Kingdom | | Uncontrollable urge to overeat (binge) | Female: 95.9% | | Sex specific death rates derived from 1981 death rates for England and Whales | BN: 0.32
Yrs followed, mean (SD): | | Self-induced vomiting or laxative abuse (Purge) | Male: 4.1% | | Analysis methods | Standardized mortality rate
AN: 7.6 (3.0) | | Feat of becoming fat | Race/ethnicity: | | Observed mortality rate (study population) | AN: 6.01 (P < 0.01) Higher than expected
BN: 5.7 (2.1) | | Exclusion: | NR | | Expected mortality rate (general population) | BN: 9.38 (P = NS)
Range: 4–15 | | NR | Mean Age of Onset (yrs): | | Standardized mortality ratio (SMR) = observed / expected | AN mortality rate (by length of FU):
| | Recruitment: | AN: 18.9 | | Stepwise linear discriminant function analysis: to examine the relationship of crude mortality to the prognostic variables | Actual mortality
| | Reviewed records of all eating disordered patients assessed in the eating disorders unit of the Academic Department of Psychiatry at Royal Free Hospital, 1971-81. | BN: 18.6 | | | Overall: 11
| | Sample Size: | Mean Duration of Illness (yrs): | | | After 4 yrs: 6
| | Initial: | AN: 3.5 | | | After 8 yrs: 1
| | N = 481 | BN: 4.9 | | | Expected mortality rate
| | Reasons for loss to FU: | 2nd Dx at Assessment: | | | Overall: 1.83
| | Lost to FU: N = 21 | Depression, N = 52 | | | After 4 yrs: 1.04
| | Deaths: N = 14 | AN: N = 26 | | | After 8 yrs: 0.37
| | AN: N = 11 | BN: N = 26 | | | Standardized mortality rate
| | Suicide: N = 6 | | | | Overall: 6.01 (P < 0.01) Higher than expected
| | Low wt: N = 5 | | | | After 4 yrs: 5.76 (P < 0.05) Higher than expected
| | BN: N = 3 | | | | After 8 yrs: 2.70 (P = NS)
| | Car accident: N = 2 | | | | Predictors of mortality in individuals with AN
| | Low wt: N = 1 | | | | wt < 35 kg at presentation:
| | Analysis sample: | | | | Crude (%): 8.1 (N = 5)
| | Located / Analyzed: N = 460 | | | | Expected: 0.33
| | AN: 332 (72.1%) | | | | Standardized: 15.15 (P < 0.05) Higher than expected
| | BN: 96 (20.9%) | | | | More than one inpatient admission:
| | Other: 32 (7.0%) | | | | Crude (%): NR
| | | | | | Expected: NR
| | | | | | Standardized: NR (P < 0.01) Higher than expected
| | | | | | Age < 20 yrs at presentation:
| | | | | | Crude (%): 2.8 (N = 4)
| | | | | | Expected: 0.41
| | | | | | Standardized: 9.76 (P = NS)
| | | | | | Age 20–29 yrs at presentation:
| | | | | | Crude (%): 2.9 (N = 4)
| | | | | | Expected: 0.56
| | | | | | Standardized: 7.09 (P = NS)
| | | | | | Age ≤ 30 yrs at presentation:
| | | | | | Crude (%): 6.0 (N = 3)
| | | | | | Expected: 0.86
| | | | | | Standardized: 3.49 (P = NS)
Authors, yr: | In an independent, community-based sample, to replicate the validity of the prior finding that women with BN can be classified by dietary and dietary-depression subtypes. | Inclusion: | Mean Age: | Score: | Study Methods: | Cluster Analysis Results
Stice and Fairburn, 2003 | | Female; met DSM IV criteria for BN; provided complete data at baseline. | 23.7 (4.9) | Fair | EDE: to asses BN and attitudinal disturbances at each time point; Depression was assessed using the BSI subscale; the SCID-I assessed current disorders at each FU; Robson Self-Esteem scale assessed general self worth. | Dietary classification: Dietary Restraint (N = 46)
Companion article: | | Exclusion: | Sex: | Method of dx: | Statistical Methods | Dietary-Depressive classification: Dietary Restraint-Depressive Affect (N = 36)
Fairburn et al., 2000 | | NR | Female: 100% | EDE was used to asses DSM IV criteria. | Iterative cluster analysis of baseline scores relating to Restraint, Depression, and Self-Esteem Scales used to categorize participants as dietary or dietary-depression subtypes. | Descriptive Results
Fairburn et al., 2003 | | Recruitment: | Race/ethnicity: | Funding: | Chi-square diffs between groups | Lifetime psychiatric tx for ED at baseline:
Design: | | Community-recruited | NR | Programme Grant, Wellcome Principal Research Fellowship, and NIMH Career Award | | Dietary: 17.4%
Prospective Cohort | | Sample Size: | Social Class | | | Dietary-depressive: 38.9%
Comparison Group: | | Baseline: | Social Class I or II (high): 47% | | | Diff between groups RR = 2.24 (P < 0.05)
No | | (N = 102) | Social Class III (middle): 45% | | | Psychiatric tx for ED during FU:
Setting: | | Reasons for loss to FU: | Social Class IV or V (low): 9% | | | Dietary: 17.4%
United Kingdom | | NR | Mean BMI, kg/m²: | | | Dietary-depressive: 30.6%
Yrs followed: | | Analysis sample: | 24.3 (4.6) | | | Diff between groups RR = 1.76 (P = NS)
At 15 mo intervals for 5 yrs. | | (N = 82) | Received prior tx for ED at baseline: | | | BN symptoms: Persistence of binge eating:
Final FU: | | Dietary: | 27% | | | Dietary: 43.9%
5.0 yrs (0.3) | | Dietary Restraint (N = 46) | | | | Dietary-depressive: 67.7%
| | Dietary-Depressive: Dietary Restraint- Depressive Affect | | | | Diff between groups RR = 1.54 (P < 0.044)
| | (N = 36) | | | | BN symptoms: Persistence of compensatory behaviors:
| | | | | | Dietary: 57.1%
| | | | | | Dietary-depressive: 60.6%
| | | | | | Diff between groups RR = 1.06 (P = NS)
| | | | | | Major depression dx
| | | | | | Dietary: 60.9%
| | | | | | Dietary-depressive: 80.6%
| | | | | | Diff between groups RR = 1.32 (P < 0.05)
| | | | | | Panic disorder dx
| | | | | | Dietary: 15.2%
| | | | | | Dietary-depressive: 33.3%
| | | | | | Diff between groups RR = 2.19 (P < 0.05)
| | | | | | OCD dx
| | | | | | Dietary: 2.2%
| | | | | | Dietary-depressive: 25.0%
| | | | | | Diff between groups RR = 11.32 (P < 0.01)
| | | | | | Social phobia dx
| | | | | | Dietary: 15.2%
| | | | | | Dietary-depressive: 33.3%
| | | | | | Diff between groups RR = 2.19 (P < 0.05)
| | | | | | Generalized anxiety disorder dx
| | | | | | Dietary: 10.9%
| | | | | | Dietary-depressive: 47.2%
| | | | | | Diff between groups RR = 4.33 (P < 0.001)
| | | | | | Agoraphobia dx
| | | | | | Dietary: 4.3%
| | | | | | Dietary-depressive: 36.1%
| | | | | | Diff between groups RR = 8.39 (P < 0.001)

Evidence Table 17. BED outcomes

Study Description | Research Objective | Eligibility Criteria, Recruitment and Sample Size | Demographic and Other Characteristics | Quality | Study Methods and Analytic Strategy | Main Outcomes and Results
Authors, yr: | To investigate 5 yr outcome of morbidly obese patients with BED treated surgically with LAGB. | Inclusion: | Age, mean (SD): | Score: | Study Methods: | Descriptive Results:
Busetto et al., 2005 | | Cases: BED dx based on proposed diagnostic criteria of DSM IV | Cases: 36.0 (10.3) | Fair | All participants underwent the same LAPD surgery, and followed the same modified liquid diet for 4 wks, followed by a solid food diet. Band adjustments were not performed before 3 mos post-surgery. All patients with BED received brief course of psychological therapy before LAGB and psychological support was offered as needed during FU. | Diff % excess wt loss (EWL) at any time after surgery (P= NS)
Design: | | Comparisons: Obese non-BED patients selected according to the inclusion criteria standardized by the NIH for obesity. | Comparisons: 38.3 (10.9) | Method of dx: | Statistical Methods: | 5 yr FU:
Case series | | Exclusion: | (P < 0.05) | Independent clinical interviews | Paired t-test for comparisons of pre- and post-surgery. | % of patients with % EWL >50%:
Comparison Group: | | NR | Height, m, mean (SD): | Funding: | t-tests and Chi-square tests for comparisons across groups | Cases: 23.1%
Yes | | Recruitment of cases and comparisons: | Cases: 1.66 (0.09) | NR | | Comparisons: 25.7%
Location: | | Homogeneous cohort of morbidly obese patients who underwent LAGB surgery at the University of Padova between January 1996 and December 1998. | Comparisons: 1.66 (0.09) | | | (P = NR)
Padova, Italy | | Sample Size: | (P = NS) | | | % patients with %EWL < 20%:
Yrs followed: 5 | | 379 morbidly obese patients | Wt, kg mean (SD): | | | Cases: 23.8%
| | Including: | Cases: 129.4 (23.9) | | | Comparisons: 24.1%
| | - Cases (BED): N = 130; - Comparisons (No BED): N = 249 | Comparisons: 132.2 (24.2) | | | Diff between groups (P = NR)
| | | (P = NS) | | | % of patients with wt regain (at least 20% of baseline excess wt):
| | | BMI, kg/m2, mean (SD): | | | Cases: 20.8%
| | | Cases: 47.6 (7.4) | | | Comparisons: 22.5%
| | | Comparisons: 46.6 (7.3) | | | (P = NR)
| | | (P = NS) | | | Postoperative complications at FU:
| | | Female Sex (%): | | | Band-related complications
| | | Cases: 72.9 | | | Stoma Stenosis:
| | | Comparisons: 71.5 | | | Cases: 34/130 (26.2%)
| | | (P < 0.05) | | | Comparisons: 65/249 (26.1%)
| | | Race/ethnicity: | | | (P = NS)
| | | NR | | | Pouch Dilatation
| | | Family hx of obesity (%): | | | Cases: 33/130 (25.4%)
| | | Cases: 65.4 | | | Comparisons: 44/249 (17.7%)
| | | Comparisons: 62.2 | | | (P = 0.05)
| | | (P = NS) | | | Esophageal Dilatation
| | | Current smokers (%): | | | Cases: 13/130 (10.0%)
| | | Cases: 39.2 | | | Comparisons: 12/249 (4.8%)
| | | Comparisons: 36.5 | | | (P = 0.05)
| | | (P = NS) | | | Stomach Slippage:
| | | Eating behavior | | | Cases: 11/130 (8.5%)
| | | Sweet eating (%) | | | Comparisons: 13/249 (5.2%)
| | | Cases: 43.8 | | | (P = NS)
| | | Comparisons: 43.8 | | | Erosion
| | | (P = NS) | | | Cases: 1/130 (0.8%)
| | | Night eating (%) | | | Comparisons: 3/249 (1.2%)
| | | Cases: 10.8 | | | (P = NS)
| | | Comparisons: 0.8 | | | Port-related complications:
| | | (P < 0.001) | | | Port Leakage
| | | Grazing (%) | | | Cases: 40/130 (30.8%)
| | | Cases: 49.2 | | | Comparisons: 68/249 (27.3%)
| | | Comparisons: 32.5 | | | (P = NS)
| | | (P < 0.01) | | | Port twisting
| | | | | | Cases: 1/130 (0.08%)
| | | | | | Comparisons: 1/249 (0.4%)
| | | | | | (P = NS)
| | | | | | Port Infection
| | | | | | Cases: 2/130 (1.5%)
| | | | | | Comparisons: 1/249 (0.4%)
| | | | | | (P = NS)
| | | | | | Revisional surgery requested related to pouch dilatation:
| | | | | | Cases: 33.3% 3
| | | | | | Comparisons: 4.1%
| | | | | | (P = NS)
| | | | | | Revisional surgery requested in cases of esophageal dilatation:
| | | | | | Cases: 23.1%
| | | | | | Comparisons: 8.3%
| | | | | | (P = NS)
| | | | | | Revisional Surgery:
| | | | | | Cases: 15 (11.5%)
| | | | | | Comparisons: 22 (8.8%)
| | | | | | (P = NS)
| | | | | | Band removed:
| | | | | | Cases: 7 (5.4%)
| | | | | | Comparisons: 9 (3.6%)
| | | | | | (P = NS)
| | | | | | Band repositioned:
| | | | | | Cases: 7 (5.4%)
| | | | | | Comparisons: 11 (4.4%)
| | | | | | (P = NS)
| | | | | | Revised to a secondary operation.
| | | | | | Cases: 2 (0.8%)
| | | | | | Comparisons: 11 (4.4%)
| | | | | | (P = NS)
| | | | | | Minor portrelated surgery:
| | | | | | Cases: 28 (21.5%)
| | | | | | Comparisons: 54 (21.7%)
| | | | | | (P = NS)
| | | | | | Postoperative band adjustments:
| | | | | | Cases 3.0 (2.1)
| | | | | | Comparisons 2.6 (1.9)
| | | | | | (P = 0.05)
| | | | | | Max band fill-volume after surgery:
| | | | | | Cases: 3.2 (1.2)
| | | | | | Comparisons: 2.8 (1.3)
| | | | | | (P < 0.01)
Authors, yr: | To assess 3 and 6 yr course and outcome of treated females with BED. | Inclusion: | Age at Admission, yrs, mean (SD): | Score: | Study Methods: | Discharge, N (%):
Fichter, Quadflieg, and Gnutzmann, 1998 | | DSM IV criteria for BED | 29.3 (8.4) | Fair | Tx: inpatient, behaviorally oriented tx. | Regular: 60 (89.6%)
Design: | | Exclusion: | Age of Onset, yrs, mean (SD): | Method of dx: | Assessments at admission, discharge, 3 yr (questionnaire), and 6 yr (questionnaire and phone interview) | Discontinued tx prematurely: 1 (1.5%)
Case series | | NR | 17.7 (8.9) | Self ratings on admission and discharge. Questionnaire used to determine DSM IV categories for BED, supplemented by patient charts and therapist dx. | Analytic Strategy: | Discharged prematurely: 2 (3.0%)
Comparison Group: | | Recruitment: | Sex: | Funding: | MANOVA with repeated measures. For longitudinal comparisons, only sets of data complete for all time points were analyzed. Wilcoxon matched-pair tests used when appropriate. | Discharged prematurely by mutual agreement with patient: 4 (6.0%)
No | | Of the 635 consecutive admissions for inpatient tx to Hospital for Behavioral Medicine at the Klinik Roseneck in Upper Bavaria, Germany, 68 met criteria. | Female: 100% | German Bundesministerium fur Bildung, Forschung and Technologie (BMBF) and Wilhelm-Sander-Stiftung, Munich, Germany | Codes used: | Discharge ratings by therapists, N (%):
Location: | | Sample Size: | Race/ethnicity: | | BT = Before Therapy | Sigly improved: 11 (16.4%)
Upper Bavaria, Germany | | Initial Sample | NR | | B: Beginning of therapy | Markedly improved: 37 (55.2%)
Yrs followed, mean (SD): | | N = 68 | Duration of tx, days, mean (SD): | | E: End of therapy | Slightly Improved: 16 (23.9%)
3.2 (0.8) and 6.6 (0.9) yrs after tx. | | 3 yr FU: | 76.7 (40) | | F3: 3 yr FU | Unchanged: 2 (3.0%)
| | Answered questionnaires: 61 (89.7%) | Duration of eating disturbance, ys, mean (SD): | | F6: 6 yr FU | Slightly worse: 1 (1.5%)
| | Short telephone interview: 2 (2.9%); Could not be reached: 4 (5.9%) | 11.6 (7.3) | | | Met criteria for BN at 6 yr FU: N = 5
| | Refused: 1 (1.5%) | Education, N (%): | | | BMI, kg/m ^ 2 ^ , mean (SD):
| | 6 yr FU: | < 9 yrs: 3 (4.4%) | | | B: 33.7 (9.0)
| | N = 62 | At least 9 yrs: 52 (76.5%) | | | E: 31.9 (8.7)
| | Death: 1 (1.5%) (due to extrauterine pregnancy). | At least 13 yrs: 10 (14.8%) | | | F3: 31.9 (9.9)
| | Reassessed: 67 (questionnaire and interview = 53; questionnaire and short interview = 1; interview = 9; short interview = 4) | University degree: 3 (4.4%) | | | F6: 32.7 (10.1)
| | | Axis IV (severity of psychosocial stressors) at admission, N (%): | | | Change over time (P = NR)
| | | Unspecified: 2 (3.1%) | | | BMI in 44 obese patients (BMI ≥ 30) at B, kg/m ^ 2 ^ , mean (SD)
| | | None: 2 (3.1%) | | | B: 39.0 (6.8)
| | | Minimal: 5 (7.7%) | | | E: 36.9 (6.8)
| | | Mild: 18 (27.7%) | | | F3: 37.0 (8.2)
| | | Moderate: 20 (30.8%) | | | F6: 38.3 (8.1)
| | | Severe: 14 (21.5%) | | | Change over time (P = NR)
| | | Extreme: 3 (4.6%) | | | Structured Interview for Anorexic and Bulimic Syndromes (SIAB) (N = 53):
| | | Catastrophic: 1 (1.5%) | | | SIAB Depression Scale, mean (SD):
| | | Axis V (highest level of adaptive function for mos before admission, N (%): | | | BT: 2.32 (1.0)
| | | Superior: 0 | | | B: 2.33 (0.9)
| | | Very good: 2 (3.1%) | | | E: 1.48 (0.9)
| | | Good: 11 (16.9%) | | | F3: 1.71 (0.9)
| | | Satisfactory: 27 (41.5%) | | | F6 (expert rating): 0.94 (0.8)
| | | Poor: 23 (35.4%) | | | Change over time in BT vs E and F6 (P < 0.001); vs. F3 (P < 0.01)
| | | Very Poor: 2 (3.1%) | | | Change over time in B vs E, F3, and F6 (P < 0.001)
| | | Grossly Impaired: 0 | | | Change over time in E vs F6 (P < 0.001)
| | | | | | Change over time in F3 vs F6 (P < 0.001)
| | | | | | SIAB Anxieties and Obsessions Scale, mean (SD):
| | | | | | BT: 1.32 (0.9)
| | | | | | B: 1.31 (0.8)
| | | | | | E: 0.76 (0.7)
| | | | | | F3: 1.00 (0.7)
| | | | | | F6 (expert rating): 0.46 (0.4)
| | | | | | Change over time in BT vs E and F6 (P < 0.001); vs F3 (P < 0.05)
| | | | | | Change over time in B vs E and F6 (P < 0.001); vs F3 (P < 0.01)
| | | | | | Change over time in E vs F3 (P < 0.01); vs F6 (P < 0.001)
| | | | | | Change over time in F3 vs F6 (P < 0.001)
| | | | | | SIAB Bulimic Behavior, mean (SD):
| | | | | | BT: 1.60 (0.6)
| | | | | | B: 1.48 (0.5)
| | | | | | E: 1.08 (0.4)
| | | | | | F3: 1.21 (0.6)
| | | | | | F6 (expert rating): 0.81 (0.6)
| | | | | | Change over time in BT vs E and F6 (P < 0.001); vs F3 (P < 0.01)
| | | | | | Change over time in B vs E, F3, and F6 (P < 0.001)
| | | | | | Change over time in E vs F6 (P < 0.001)
| | | | | | Change over time in F3 vs F6 (P < 0.001)
| | | | | | SIAB Laxative Abuse, mean (SD):
| | | | | | BT: 1.39 (1.3)
| | | | | | B: 0.82 (0.9)
| | | | | | E: 0.66 (0.9)
| | | | | | F3: 0.38 (0.8)
| | | | | | F6 (expert rating): 0.23 (0.6)
| | | | | | Change over time in BT vs B, E, and F3 (P < 0.001)
| | | | | | Change over time in B vs F3 (P < 0.01)
| | | | | | Change over time in B vs F6 (P < 0.01)
| | | | | | Diagnostic outcome at 6 yrs, N (%):
| | | | | | BED: 4 (5.9%)
| | | | | | BN, purging type: 5 (7.4%)
| | | | | | EDNOS: 5 (7.4%)
| | | | | | No ED: 53 (77.9%)
| | | | | | Outcomes at 6 yr FU (N = 62):
| | | | | | Body wt, N (%):
| | | | | | Good: 26 (41.9%)
| | | | | | Intermediate: 22 (35.5%)
| | | | | | Poor: 14 (22.6%)
| | | | | | (P = NR)
| | | | | | Overconcern with eating and wt, N (%):
| | | | | | Good: 22 (35.5%)
| | | | | | Intermediate: 20 (32.3%)
| | | | | | Poor: 20 (32.3%)
| | | | | | (P = NR)
| | | | | | Binge eating:
| | | | | | Good: 39 (62.9%)
| | | | | | Intermediate: 13 (21.0%)
| | | | | | Poor: 10 (16.2%)
| | | | | | (P = NR)
| | | | | | Counterregulatory measures, N (%):
| | | | | | Good: 44 (71.0%)
| | | | | | Intermediate: 11 (17.7%)
| | | | | | Poor: 10 (11.3%)
| | | | | | (P = NR)
| | | | | | Depression, N (%):
| | | | | | Good: 35 (56.5%)
| | | | | | Intermediate: 12 (19.4%)
| | | | | | Poor: 15 (24.2%)
| | | | | | (P = NR)
| | | | | | Obsessions, N (%):
| | | | | | Good: 49 (79.0%)
| | | | | | Intermediate: 10 (16.1%)
| | | | | | Poor: 3 (4.8%)
| | | | | | (P = NR)
| | | | | | Anxiety, N (%):
| | | | | | Good: 39 (62.9%)
| | | | | | Intermediate: 19 (30.6%)
| | | | | | Poor: 4 (6.5%)
| | | | | | (P = NR)
| | | | | | Substance abuse, N (%):
| | | | | | Good: 58 (93.5%)
| | | | | | Intermediate: 1 (1.6%)
| | | | | | Poor: 3 (4.8%)
| | | | | | (P = NR)
| | | | | | Sexuality, N (%):
| | | | | | Good: 24 (38.7%)
| | | | | | Intermediate: 16 (25.8%)
| | | | | | Poor: 22 (35.5%)
| | | | | | (P = NR)
| | | | | | Social Behavior, N (%):
| | | | | | Good: 32 (51.6%)
| | | | | | Intermediate: 15 (24.2%)
| | | | | | Poor: 15 (24.2%)
| | | | | | (P = NR)
| | | | | | Global outcome based on reduced sample (N = 62), N (%):
| | | | | | Good: 39 (62.9%)
| | | | | | Intermediate: 21 (33.9)
| | | | | | Poor: 2 (3.2%)
| | | | | | (P = NR)
| | | | | | Global outcome on total sample (N = 68), %:
| | | | | | Good: 57.4%
| | | | | | Intermediate: 35.3%
| | | | | | Poor: 5.9%
| | | | | | (P = NR)
| | | | | | Comorbidity at 6 yrs, %:
| | | | | | Substance use disorder: 9.7%
| | | | | | Affective disorder: 51.6%
| | | | | | Anxiety disorder: 40.3%
| | | | | | Hospitalized in the 6 yr FU period:
| | | | | | 44/67
| | | | | | Duration of stay, days, mean (SD):
| | | | | | 114 (208)
| | | | | | Number of admissions, mean (SD):
| | | | | | 1.6 (1.6)
Authors, yr: | To examine the relation of comorbid Axis I and Axis II psycho-pathology on tx outcomes at 1 yr FU among BED patients | Inclusion: | Mean Age (SD): | Score: | Study Methods: | Descriptive Findings
Wilfley, Friedman et al., 2000 | | Participated in an outpatient RCT and received either CBT or IPT conducted at 2 outpatient, university-based eating disorder clinics, one in Northeast and one in Southwest | 45.2 (9.6) | Good | EDE and SCID administered by trained and experienced interviewers | Mood disorder dx:
Design: | | DSM IV criteria for BED | Sex: | Method of dx: | Statistical Methods: | Current: 22%
Case series | | ages 18-65 | Women: 83% | BED: EDE interview | Repeated measures MANOVAs to assess whether the presence of Axis I or Axis II pathology predicts BED outcome at 1-yr FU. | Lifetime61%
Comparison Group: | | BMI (kg/m^2^):27-48 | Race/ethnicity: | Comorbid Axis I and Axis II disorders: SCID and the SCID-II | Dependent variables: | Anxiety disorder dx:
No | | Exclusion: | Caucasian: 93% | Funding: | # of binge days | Current: 13%
Location: | | Inappropriate compensatory behaviors; pregnant or planning to become pregnant; participating in additional psychotherapy or wt loss programs; currently taking wt loss, psychotropic, or wt-affecting prescription meds; current drug or alcohol dependence; current psychiatric conditions warranting hospitalization | African American: 4% | NIMH grants | EDE Global Scale of Eating Psychopathology | Lifetime29%
USA | | Recruitment: | Hispanic: 3% | | | Substance abuse dx:
Yrs followed: 1 | | Newspaper articles and ads | Native American: 1% | | | Current: 4%
| | Sample Size: | Marital status: | | | Lifetime33%
| | Participated in RCT, N = 162 | Married: 60% | | | Interaction of Time X presence of Axis I psychopathology (i.e., mood, anxiety, and substance abuse disorders) predicting:
| | # of completers at 1-yr FU: | Single: 15% | | | # of binge days (P = NS)
| | NR | Divorced: 24% | | | EDE Global Scale of Eating Psychopathology (P = NS)
| | | Widowed: 2% | | | Interaction of Time x Presence of Axis II psychopathology (i.e., cluster A, B, and C) predicting:
| | | Education (mean): | | | # of binge day (P = NS)
| | | 15.6 yrs | | | EDE Global Scale of Eating Psychopathology (P = NS)
| | | Mean Income range: | | | Interaction of Time X Presence of specific Axis I psychopathology predicting:
| | | $40,000-$50,000 | | | # of binge days (P = NS)
| | | Comorbid Axis I general dx (current): | | | EDE Global Scale of Eating Psychopathology (P = NS)
| | | Mood disorders: 22% | | | Interaction of Time X Presence of Axis II Cluster A (Paranoid, schizoid, schizotypal) predicting:
| | | Anxiety disorders: 13% | | | # of binge days (P = NS)
| | | Substance abuse disorders: 4% | | | EDE Global Scale of Eating Psychopathology (P = NS)
| | | Comorbid Axis I general dx (lifetime): | | | Interaction of Time X Presence of Axis II Clusters B (narcissistic, borderline, histrionic, antisocial) predicting:
| | | Mood disorders: 61% | | | # of binge days (P = 0.022) Those with Cluster B > # of binge days
| | | Anxiety disorders: 29% | | | EDE Global Scale of Eating Psychopathology (P = NS)
| | | Substance abuse disorders: 33% | | | Interaction of Time X Presence of Axis II Cluster C (dependent, obsessive-compulsive, avoidant, passive-aggressive) predicting:
| | | Comorbid Axis II: | | | # of binge days (P = NS)
| | | Cluster A: 6% | | | EDE Global Scale of Eating Psychopathology (P = NS)
| | | Cluster B: 12%
| | | Cluster C: 42%
| | | Personality disorder NOS: 13%
| | | Avg. BMI (kg/m ^ 2 ^ ) (SD):
| | | 37.1 (5.1)