# Appendix B. Sample Data Collection Forms

## Eating Disorders Outcomes Quality Rating Form (__points)

## Quality Review Form for Eating Disorder RCTs