# Appendix A. Exact Search Strings

## Search Strategy

#3 | Search “Eating Disorders”[MeSH] | 17336
#4 | Search “Eating Disorders”[MeSH] Field: All Fields, Limits: Randomized Controlled Trial | 467
#6 | Search “Anorexia”[MeSH] OR “Anorexia Nervosa”[MeSH] | 9631
#7 | Search “Anorexia”[MeSH] OR “Anorexia Nervosa”[MeSH] Field: All Fields, Limits: Randomized Controlled Trial | 195
#11 | Search “Bulimia”[MeSH] | 3624
#12 | Search “Bulimia”[MeSH] Field: All Fields, Limits: Randomized Controlled Trial | 210
#14 | Search “Therapeutics”[MeSH] | 1607160
#23 | Search “Cognitive Therapy”[MeSH] OR “Family Therapy”[MeSH] OR “Drug Therapy”[MeSH] OR “Therapy, Computer-Assisted”[MeSH] | 289583
#34 | Search “Randomized Controlled Trials”[MeSH] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] | 157518
#35 | Search #3 AND #34 | 306
#36 | Search #6 AND #34 | 146
#37 | Search #11 AND #34 | 130
#39 | Search #36 OR #7 | 272
#40 | Search #38 OR #12 | 624
#41 | Search #23 OR #14 | 1614410
#42 | Search #41 AND #35 | 111
#43 | Search #41 AND #36 | 45
#44 | Search #41 AND #37 | 49
#45 | Search relapse | 130475
#48 | Search “Recurrence”[MeSH] OR “Patient Readmission”[MeSH] | 103204
#49 | Search #48 AND #4 | 18
#50 | Search #48 AND #6 | 95
#51 | Search #48 AND #11 | 68
#54 | Search “Outcome Assessment (Health Care)”[MeSH] OR “Treatment Outcome”[MeSH] OR “Outcome and Process Assessment (Health Care)”[MeSH] | 236323
#55 | Search #54 AND #4 | 139
#56 | Search #54 AND #6 | 341
#57 | Search #54 AND #11 | 304
#58 | Search “binge eating” | 1240
#59 | Search #58 AND #34 | 50
#60 | Search #58 AND #41 | 335
#61 | Search #58 AND #48 | 22
#65 | Search #60 AND #59 | 2
#69 | Search #12 OR #37 | 274
#3 | Search “Eating Disorders”[MeSH] | 17336
#4 | Search “Eating Disorders”[MeSH] Field: All Fields, Limits: Randomized Controlled Trial | 467
#6 | Search “Anorexia”[MeSH] OR “Anorexia Nervosa”[MeSH] | 9631
#7 | Search “Anorexia”[MeSH] OR “Anorexia Nervosa”[MeSH] Field: All Fields, Limits: Randomized Controlled Trial | 195
#11 | Search “Bulimia”[MeSH] | 3624
#12 | Search “Bulimia”[MeSH] Field: All Fields, Limits: Randomized Controlled Trial | 210
#14 | Search “Therapeutics”[MeSH] | 1607160
#23 | Search “Cognitive Therapy”[MeSH] OR “Family Therapy”[MeSH] OR “Drug Therapy”[MeSH] OR “Therapy, Computer-Assisted”[MeSH] | 289583
#24 | Search #3 AND #23 | 789
#25 | Search #6 AND #23 | 463
#26 | Search #11AND #23 | 0
#27 | Search #11 AND #23 | 291
#34 | Search “Randomized Controlled Trials”[MeSH] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] | 157518
#35 | Search #3 AND #34 | 306
#36 | Search #6 AND #34 | 146
#37 | Search #11 AND #34 | 130
#39 | Search #36 OR #7 | 272
#40 | Search #38 OR #12 | 624
#41 | Search #23 OR #14 | 1614410
#42 | Search #41 AND #35 | 111
#43 | Search #41 AND #36 | 45
#44 | Search #41 AND #37 | 49
#45 | Search relapse | 130475
#48 | Search “Recurrence”[MeSH] OR “Patient Readmission”[MeSH] | 103204
#49 | Search #48 AND #4 | 18
#50 | Search #48 AND #6 | 95
#51 | Search #48 AND #11 | 68
#54 | Search “Outcome Assessment (Health Care)”[MeSH] OR “Treatment Outcome”[MeSH] OR “Outcome and Process Assessment (Health Care)”[MeSH] | 236323
#55 | Search #54 AND #4 | 139
#56 | Search #54 AND #6 | 341
#57 | Search #54 AND #11 | 304
#58 | Search “binge eating” | 1240
#59 | Search #58 AND #34 | 50
#60 | Search #58 AND #41 | 335
#61 | Search #58 AND #48 | 22
#65 | Search #60 AND #59 | 25
#66 | Search #48 AND #3 | 186
#67 | Search #54 AND #3 | 680
#68 | Search #54 AND #58 | 134

## Extra Numbers

#1 | Search outcomes | 96219
#10 | Search “Outcome Assessment (Health Care)”[MeSH] OR “Fatal Outcome”[MeSH] OR “Treatment Outcome”[MeSH] OR “Outcome and Process Assessment (Health Care)”[MeSH] OR “Weight Gain”[MeSH] OR “Osteoporosis”[MeSH] OR “Tooth Diseases”[MeSH] OR “Suicide”[MeSH] OR “Stomach Diseases”[MeSH] | 511077
#17 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials”[MeSH] OR “Double-Blind Method”[MeSH] OR “Single-Blind Method”[MeSH] AND “Random Allocation”[MeSH] OR “Longitudinal Studies”[MeSH]OR Observational Study | 492971

## Harms Search

#1 | Search anorexia [mh] OR anorexia nervosa [mh] or bulimia [mh] or “binge eating disorder” [tw] OR eating disorders [mh] OR “binge eating” [tw] | 17671
#2 | Search coprophagia [mh] OR hyperphagia [mh] OR pica [mh] | 2392
#3 | Search #1 NOT #2 | 15279
#4 | Search adverse effects [subheading] OR harms [tw] OR “side effects” [tw] OR “adverse effects” [tw] OR death [mh] OR drug hypersensitivity [mh] OR drug toxicity [mh] OR seizures [mh] | 1211380
#5 | Search #3 AND #4 | 1675
#6 | Search therapeutics [mh] OR therapy [subheading] | 3923801
#7 | Search #5 AND #6 | 1228

## Other Terms Search

#4 | Search “Eating Disorders”[MeSH]OR “binge eating” [tw] | 17669
#8 | Search (“Anorexia”[MeSH] OR “Anorexia Nervosa”[MeSH]) OR “Bulimia”[MeSH] OR “binge eating disorder” [tw] | 11821
#9 | Search #4 NOT #8 | 5848
#10 | Search #4 NOT #8 Field: All Fields, Limits: Randomized Controlled Trial | 99
#15 | Search (“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials”[MeSH]) OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] | 277468
#16 | Search #9 AND #15 | 133
#17 | Search #10 OR #16 | 133
#18 | Search longitudinal studies [mh] OR observational study [mh] | 472680
#20 | Search #18 AND #9 | 291
#21 | Search #20 OR #16 | 400
#27 | Search “Cognitive Therapy”[MeSH] OR “Therapeutics”[MeSH] OR “Family Therapy”[MeSH] OR “Drug Therapy”[MeSH] OR “Therapy, Computer-Assisted”[MeSH] | 1640745
#28 | Search #27 AND #9 | 910
#29 | Search #28 NOT #8 | 910
#30 | Search #28 NOT #8 Field: All Fields, Limits: 5 Years | 277
#31 | Search #28 NOT #30 | 633
#32 | Search #28 NOT #30 Field: All Fields, Limits: 10 Years | 194
#33 | Search #31 NOT #32 | 439
#37 | Search “Recurrence”[MeSH] OR “Patient Readmission”[MeSH] | 104066
#38 | Search #9 AND #37 | 49
#45 | Search (“Outcome Assessment (Health Care)”[MeSH] OR “Treatment Outcome”[MeSH] OR “Outcome and Process Assessment (Health Care)”[MeSH]) OR “Weight Gain”[MeSH] OR “Osteoporosis”[MeSH] OR “Tooth Diseases”[MeSH] OR “Suicide”[MeSH] OR “Stomach Diseases”[MeSH] | 494808
#46 | Search #9 AND #45 | 482
#50 | Search “Coprophagia”[MeSH] OR “Hyperphagia”[MeSH] OR “Pica”[MeSH] | 2392
#51 | Search #9 NOT #50 | 3922
#52 | Search #9 NOT #50 Field: All Fields, Limits: Randomized Controlled Trial | 70
#53 | Search #15 AND #51 Limits: Randomized Controlled Trial | 70
#54 | Search #52 OR #53 Limits: Randomized Controlled Trial | 70
#55 | Search #51 AND #18 Limits: Randomized Controlled Trial | 15
#56 | Search #51 AND #18 Field: All Fields | 236