# Appendixes

Appendix A. Exact Search Strings

Appendix B. Sample Data Collection Forms

Appendix C. Evidence Tables

Appendix D. List of Excluded Articles

Appendix E. Acknowledgments