# References and Included Studies

References

1 Cowan WM, Kandel ER. Prospects for neurology and psychiatry. JAMA. 2001;285(5):594-600. [pmid: 11176865].
2 Martin JB. Molecular basis of the neurodegenerative disorders. N Engl J Med. 1999;340(25):1970-1980. [pmid: 10379022].
3 Nussbaum RL, Ellis CE. Alzheimer's disease and Parkinson's disease. N Engl J Med. 2003;348(14):1356-1364. [pmid: 12672864].
4 Hy LX, Keller DM. Prevalence of AD among whites: a summary by levels of severity. Neurology. 2000;55(2):198-204. [pmid: 10908890].
5 Blacker D, Albert MS, Bassett SS, et al. Reliability and validity of NINCDS-ADRDA criteria for Alzheimer's disease. The National Institute of Mental Health Genetics Initiative. Arch Neurol. 1994;51(12):1198-1204. [pmid: 7986174].
6 Lang AE, Lozano AM. Parkinson's disease. First of two parts. N Engl J Med. 1998;339(15):1044-1053. [pmid: 9761807].
7 Tanner CM, Goldman SM. Epidemiology of Parkinson's disease. Neurol Clin. 1996;14(2):317-335. [pmid: 8827174].
8 Przedborski S, Vila M, Jackson-Lewis V. Neurodegeneration: what is it and where are we?. J Clin Invest. 2003;111(1):3-10. [pmid: 12511579]. [pmcid: 151843].
9 Herrmann N. Cognitive pharmacotherapy of Alzheimer's disease and other dementias. Can J Psychiatry. 2002;47(8):715-722. [pmid: 12420649].
10 Hardy J. Amyloid, the presenilins and Alzheimer's disease. Trends Neurosci. 1997;20(4):154-159. [pmid: 9106355].
11 Mattson MP, Chan SL, Duan W. Modification of brain aging and neurodegenerative disorders by genes, diet, and behavior. Physiol Rev. 2002;82(3):637-672. [pmid: 12087131].
12 Ibanez P, Bonnet AM, Debarges B, et al. Causal relation between alpha-synuclein gene duplication and familial Parkinson's disease. Lancet. 2004;364(9440):1169-1171. [pmid: 15451225].
13 Meydani M. Antioxidants and cognitive function. Nutr Rev. 2001;59(8 Pt 2):S75-S80. [pmid: 11519672].
14 Floyd RA. Antioxidants, oxidative stress, and degenerative neurological disorders. Proc Soc Exp Biol Med. 1999;222(3):236-245. [pmid: 10601882].
15 Durany N, Munch G, Michel T, Riederer P. Investigations on oxidative stress and therapeutical implications in dementia. Eur Arch Psychiatry Clin Neurosci. 1999;249(Suppl 3):68-73. [pmid: 10654103].
16 Behl C. Alzheimer's disease and oxidative stress: implications for novel therapeutic approaches. Prog Neurobiol. 1999;57(3):301-323. [pmid: 10096843].
17 Butterfield DA, Howard B, Yatin S, et al. Elevated oxidative stress in models of normal brain aging and Alzheimer's disease. Life Sci. 1999;65(1819):1883-1892. [pmid: 10576432].
18 Seshadri S, Beiser A, Selhub J, et al. Plasma homocysteine as a risk factor for dementia and Alzheimer's disease. N Engl J Med. 2002;346(7):476-483. [pmid: 11844848].
19 Wardlaw GM, Kessel M. The Water-Soluble Vitamins. Perspectivs in Nutrition - 5th ed. New York: McGraw-Hill, 2002: 364–417.
20 Rodriguez-Martin JL, Lopez-Arrieta JM, Qizilbash N. Thiamine for Alzheimer's disease. Cochrane Database Syst Rev 2000;(2):CD001498.
21 Rodriguez-Martin JL, Qizilbash N, Lopez-Arrieta JM. Thiamine for Alzheimer's disease. Cochrane Database Syst Rev 2001;(2):CD001498.
22 Kretsch MJ, Sauberlich HE, Newbrun E. Electroencephalographic changes and periodontal status during short-term vitamin B-6 depletion of young, nonpregnant women. Am J Clin Nutr. 1991;53(5):1266-1274. [pmid: 2021133].
23 Canham JE, Baker EM, Harding RS, Sauberlich HE, Plough IC. Dietary protein—its relationship to vitamin B6 requirements and function. Ann NY Acad Sci. 1969;166(1):16-29. [pmid: 5262013].
24 Riggs KM, Spiro A, III, Tucker K, Rush D. Relations of vitamin B-12, vitamin B-6, folate, and homocysteine to cognitive performance in the Normative Aging Study. Am J Clin Nutr. 1996;63(3):306-314. [pmid: 8602585].
25 Wang HX, Wahlin A, Basun H, et al. Vitamin B(12) and folate in relation to the development of Alzheimer's disease. Neurology. 2001;56(9):1188-1194. [pmid: 11342684].
26 Duan W, Ladenheim B, Cutler RG, et al. Dietary folate deficiency and elevated homocysteine levels endanger dopaminergic neurons in models of Parkinson's disease. J Neurochem. 2002;80(1):101-110. [pmid: 11796748].
27 Kruman II, Kumaravel TS, Lohani A, et al. Folic acid deficiency and homocysteine impair DNA repair in hippocampal neurons and sensitize them to amyloid toxicity in experimental models of Alzheimer's disease. J Neurosci. 2002;22(5):1752-1762. [pmid: 11880504].
28 Hyson D. The health benefits of fruits and vegetables: A review of the literature from 1999 to 2001. 2002. Produce for Better Health Foundation.
29 Casadesus G, Shukitt-Hale B, Joseph JA. Qualitative versus quantitative caloric intake: are they equivalent paths to successful aging?. Neurobiol Aging. 2002;23(5):747-769. [pmid: 12392779].
30 Youdim KA, Joseph JA. A possible emerging role of phytochemicals in improving age-related neurological dysfunctions: a multiplicity of effects. Free Radic Biol Med. 2001;30(6):583-594. [pmid: 11295356].
31 Kalat JW, Rozin P. “Learned safety” as a mechanism in long-delay taste-aversion learning in rats. J Comp Physiol Psychol. 1973;83(2):198-207. [pmid: 4706590].
32 Balk EM, Bonis PA, Moskowitz H, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. 2002;287(22):2973-2982. [pmid: 12052127].
33 National Kidney Foundation. K/DOQI clinical practice guidelines for chronic kidney disease: evaluation, classification, and stratification. Kidney Disease Outcome Quality Initiative. Am J Kidney Dis 2002; 39(2:Suppl 2):Suppl-246.
34 Ciccia RM, Langlais PJ. An examination of the synergistic interaction of ethanol and thiamine deficiency in the development of neurological signs and long-term cognitive and memory impairments. Alcohol Clin Exp Res. 2000;24(5):622-634. [pmid: 10832903].
35 Jolicoeur FB, Rondeau DB, Barbeau A, Wayner MJ. Comparison of neurobehavioral effects induced by various experimental models of ataxia in the rat. Neurobehav Toxicol. 1979;1(S1):175-178. [pmid: 299576].
36 Jolicoeur FB, Rondeau DB, Hamel E, Butterworth RF, Barbeau A. Measurement of ataxia and related neurological signs in the laboratory rat. Can J Neurol Sci. 1979;6(2):209-215. [pmid: 487313].
37 Masuda Y, Kokubu T, Yamashita M, Ikeda H, Inoue S. EGG phosphatidylcholine combined with vitamin B12 improved memory impairment following lesioning of nucleus basalis in rats. Life Sci. 1998;62(9):813-822. [pmid: 9496699].
38 Terasawa M, Nakahara T, Tsukada N, Sugawara A, Itokawa Y. The relationship between thiamine deficiency and performance of a learning task in rats. Metabol Brain Dis. 1999;14(3):137-148.
39 Zimitat C, Kril J, Harper CG, Nixon PF. Progression of neurological disease in thiamin-deficient rats is enhanced by ethanol. Alcohol. 1990;7(6):493-501. [pmid: 2261086].
40 Kim JM, Lee H, Chang N. Hyperhomocysteinemia due to short-term folate deprivation is related to electron microscopic changes in the rat brain. J Nutr. 2002;132(11):3418-3421. [pmid: 12421861].
41 Driskell JA, Strickland LA, Poon CH, Foshee DP. The vitamin B6 requirement of the male rat as determined by behavioral patterns, brain pyridoxal phosphate and nucleic acid composition and erythrocyte alanine aminotransferase activity. J Nutr. 1973;103(5):670-680. [pmid: 4710079].
42 Tunnicliff G, Wimer RE, Roberts E. Pyridoxine dietary levels and open-field activity of inbred mice. Brain Res. 1972;42(1):234-238. [pmid: 5047194].
43 Collins GH, Converse WK. Cerebellar degeneration in thiamine-deficient rats. Am J Pathol. 1970;58(2):219-233. [pmid: 4908519]. [pmcid: 2032823].
44 Ezer E, Szporny L. Tape test as a simple new method for the study of compounds increasing the problem-solving ability of the rat. Psychopharmacology. 1976;48(1):97-99. [pmid: 135270].
45 Gospe SM Jr., Gietzen DW, Summers PJ, et al. Behavioral and neurochemical changes in folate-deficient mice. Physiol Behav. 1995;58(5):935-941. [pmid: 8577891].
46 Guilarte TR, Miceli RC, Moran TH. Developmental effects of vitamin B-6 restriction on the locomotor behavior of rats. Brain Res Bull. 1991;26(6):857-861. [pmid: 1933406].
47 Nakagawasai O, Tadano T, Niijima F, TanNo K, Kisara K. Immunohistochemical estimation of rat brain somatostatin on avoidance learning impairment induced by thiamine deficiency. Brain Res Bull. 2000;51(1):47-55. [pmid: 10654580].
48 Robertson DM, Wasan SM, Skinner DB. Ultrastructural features of early brain stem lesions of thiamine-deficient rats. Am J Pathol. 1968;52(5):1081-1097. [pmid: 5646511]. [pmcid: 2013350].
49 Sasaki H, Matsuzaki Y, Meguro K, et al. Vitamin B12 improves cognitive disturbance in rodents fed a choline-deficient diet. Pharmacol Biochem Behav. 1992;43(2):635-639. [pmid: 1438503].
50 Sasaki H, Meguro K, Matsuzaki Y, et al. Effect of nicotine on cognitive disturbance in animals with acetylcholine deficient brain. Jpn J Psychopharm. 1993;13(3):143-147.
51 Stewart CN, Coursin DB, Bhagavan HN. Avoidance behavior in vitamin B-6 deficient rats. J Nutr. 1975;105(11):1363-1370. [pmid: 1185281].
52 Shea TB, Rogers E. Folate quenches oxidative damage in brains of apolipoprotein E-deficient mice: augmentation by vitamin E. Brain Res Mol Brain Res. 2002;108(12):1-6. [pmid: 12480173].
53 Shea TB, Rogers E, Ashline D, Ortiz D, Sheu MS. Apolipoprotein E deficiency promotes increased oxidative stress and compensatory increases in antioxidants in brain tissue. Free Radic Biol Med. 2002;33(8):1115-1120. [pmid: 12374623].
54 Shea TB, Rogers E, Ashline D, et al. Vitamin E deficiency does not induce compensatory antioxidant increases in central nervous system tissue of apolipoprotein E-deficient mice. J Alzheimers Dis. 2003;5(1):9-14. [pmid: 12590161].
55 Fuso A, Seminara L, Cavallaro RA, D'Anselmi F, Scarpa S. S-adenosylmethionine/homocysteine cycle alterations modify DNA methylation status with consequent deregulation of PS1 and BACE and beta-amyloid production. Mol Cell Neurosci. 2005;28(1):195-204. [pmid: 15607954].
56 Lee H, Kim HJ, Kim JM, Chang N. Effects of dietary folic acid supplementation on cerebrovascular endothelial dysfunction in rats with induced hyperhomocysteinemia. Brain Res. 2004;996(2):139-147. [pmid: 14697491].
57 Lee H, Kim JM, Kim HJ, Lee I, Chang N. Folic acid supplementation can reduce the endothelial damage in rat brain microvasculature due to hyperhomocysteinemia. J Nutr. 2005;135(3):544-548. [pmid: 15735091].
58 Warnock LG, Burkhalter VJ. Evidence of malfunctioning blood-brain barrier in experimental thiamine deficiency in rats. J Nutr. 1968;94(2):256-260. [pmid: 5637221].
59 Manz HJ, Robertson DM. Vascular permeability to horseradish peroxidase in brainstem lesions of thiamine-deficient rats. Am J Pathol. 1972;66(3):565-576. [pmid: 5060583]. [pmcid: 2032735].
60 Robertson DM, Manz HJ. Effect of thiamine deficiency on the competence of the blood-brain barrier to albumin labeled with fluorescent dyes. Am J Pathol. 1971;63(3):393-402. [pmid: 5581230]. [pmcid: 2047487].
61 Blass JP, Gleason P, Brush D, DiPonte P, Thaler H. Thiamine and Alzheimer's disease. A pilot study. Arch Neurol. 1988;45(8):833-835. [pmid: 2969232].
62 Meador K, Loring D, Nichols M, et al. Preliminary findings of high-dose thiamine in dementia of Alzheimer's type. J Geriatr Psychiatry Neurol. 1993;6(4):222-229. [pmid: 8251051].
63 Nolan KA, Black RS, Sheu KF, Langberg J, Blass JP. A trial of thiamine in Alzheimer's disease. Arch Neurol. 1991;48(1):81-83. [pmid: 1986730].
64 Mimori Y, Katsuoka H, Nakamura S. Thiamine therapy in Alzheimer's disease. Metab Brain Dis. 1996;11(1):89-94. [pmid: 8815393].
65 Bryan J, Calvaresi E, Hughes D. Short-term folate, vitamin B-12 or vitamin B-6 supplementation slightly affects memory performance but not mood in women of various ages. J Nutr. 2002;132(6):1345-1356. [pmid: 12042457].
66 Deijen JB, van der Beek EJ, Orlebeke JF, van den BH. Vitamin B-6 supplementation in elderly men: effects on mood, memory, performance and mental effort. Psychopharmacology. 1992;109(4):489-496. [pmid: 1365868].
67 Abyad A. Prevalence of vitamin B12 deficiency among demented patients and cognitive recovery with cobalamin replacement. J Nutr Health Aging. 2002;6(4):254-260. [pmid: 12486445].
68 Carmel R, Gott PS, Waters CH, et al. The frequently low cobalamin levels in dementia usually signify treatable metabolic, neurologic and electrophysiologic abnormalities. Eur J Haematology. 1995;54(4):245-253.
69 Hvas AM, Juul S, Lauritzen L, Nexo E, Ellegaard J. No effect of vitamin B-12 treatment on cognitive function and depression: a randomized placebo controlled study. J Affect Disord. 2004;81(3):269-273. [pmid: 15337331].
70 Ikeda T, Yamamoto K, Takahashi K, et al. Treatment of Alzheimer-type dementia with intravenous mecobalamin. Clin Ther. 1992;14(3):426-437. [pmid: 1638584].
71 Ito T, Yamadera H, Ito R, et al. Effects of vitamin B12 on bright light on cognitive and sleep-wake rhythm in Alzheimer-type dementia. Psychiatry Clin Neurosci. 2001;55(3):281-282. [pmid: 11422876].
72 Kral VA, Solyom L, Enesco H, Ledwidge B. Relationship of vitamin B12 and folic acid to memory function. Biol Psychiatry. 1970;2(1):19-26. [pmid: 5414901].
73 Kwok T, Tang C, Woo J, et al. Randomized trial of the effect of supplementation on the cognitive function of older people with subnormal cobalamin levels. Int J Geriatr Psychiatry. 1998;13(9):611-616. [pmid: 9777425].
74 Martin DC, Francis J, Protetch J, Huff FJ. Time dependency of cognitive recovery with cobalamin replacement: report of a pilot study. J Am Geriatr Society. 1992;40(2):168-172.
75 Mitsuyama Y, Kogoh H. Serum and cerebrospinal fluid vitamin B12 levels in demented patients with CH3-B12 treatment—preliminary study. Jpn J Psychiatry Neurol. 1988;42(1):65-71. [pmid: 3398357].
76 Seal EC, Metz J, Flicker L, Melny J. A randomized, double-blind, placebo-controlled study of oral vitamin B12 supplementation in older patients with subnormal or borderline serum vitamin B12 concentrations. J Am Geriatr Soc. 2002;50(1):146-151. [pmid: 12028259].
77 Teunisse S, Bollen AE, van Gool WA, Walstra GJ. Dementia and subnormal levels of vitamin B12: effects of replacement therapy on dementia. J Neurol. 1996;243(7):522-529. [pmid: 8836942].
78 van Asselt DZ, Pasman JW, van Lier HJ, et al. Cobalamin supplementation improves cognitive and cerebral function in older, cobalamin-deficient persons. J Gerontol A Biol Sci Med Sci. 2001;56(12):M775-M779. [pmid: 11723153].
79 Sommer BR, Hoff AL, Costa M. Folic acid supplementation in dementia: a preliminary report. J Geriatr Psychiatry Neurol. 2003;16(3):156-159. [pmid: 12967058].
80 Fioravanti M, Ferrario E, Massaia M, et al. Low folate levels in the cognitive decline of elderly patients and the efficacy of folate as a treatment for improving memory deficits. Arch Gerontol and Geriatrics. 1997;26(1):1-13.
81 McGeer PL, Zeldowicz L, McGeer EG. A clinical trial of folic acid in Parkinson's disease. Can Med Assoc J. 1972;106(2):145-146. [pmid: 4400558]. [pmcid: 1940357].
82 Rapin JR, LePoncin M, Grebyl J. Blood folates deficiencies and cognitive functions in aging. Trends Biomed Gerontol. 1988;1:315-323.
83 Clarke R, Harrison G, Richards S. Vital Trial Collaborative Group. Effect of vitamins and aspirin on markers of platelet activation, oxidative stress and homocysteine in people at high risk of dementia. J Intern Med. 2003;254(1):67-75. [pmid: 12823643].
84 Lewerin C, Matousek M, Steen G, et al. Significant correlations of plasma homocysteine and serum methylmalonic acid with movement and cognitive performance in elderly subjects but no improvement from short-term vitamin therapy: a placebo-controlled randomized study. Am J Clin Nutr. 2005;81(5):1155-1162. [pmid: 15883442].
85 Shaw DM, Macsweeney DA, Johnson AL, et al. Folate and amine metabolites in senile dementia: a combined trial and biochemical study. Psychol Med. 1971;1(2):166-171. [pmid: 5148767].
86 Aisen PS, Egelko S, Andrews H, et al. A pilot study of vitamins to lower plasma homocysteine levels in Alzheimer disease. Am J Geriatr Psychiatry. 2003;11(2):246-249. [pmid: 12611755].
87 Lehmann M, Regland B, Blennow K, Gottfries CG. Vitamin B12-B6-folate treatment improves blood-brain barrier function in patients with hyperhomocysteinaemia and mild cognitive impairment. Dement Geriatr Cogn Disord. 2003;16(3):145-150. [pmid: 12826740].
88 Nilsson K, Gustafson L, Hultberg B. Improvement of cognitive functions after cobalamin/folate supplementation in elderly patients with dementia and elevated plasma homocysteine. Int J Geriatr Psychiatry. 2001;16(6):609-614. [pmid: 11424170].
89 Chen H, Zhang SM, Schwarzschild MA, et al. Folate intake and risk of Parkinson's disease. Am J Epidemiol. 2004;160(4):368-375. [pmid: 15286022].
90 Deijen JB, Slump E, Wouters-Wesseling W, et al. Nutritional intake and daily functioning of psychogeriatric nursing home residents. J Nutr Health Aging. 2003;7(4):242-246. [pmid: 12917748].
91 Mizrahi EH, Jacobsen DW, Debanne SM, et al. Plasma total homocysteine levels, dietary vitamin B6 and folate intake in AD and healthy aging. J Nutr Health Aging. 2003;7(3):160-165. [pmid: 12766793].
92 Goodwin JS, Goodwin JM, Garry PJ. Association between nutritional status and cognitive functioning in a healthy elderly population. JAMA. 1983;249(21):2917-2921. [pmid: 6842805].
93 Lee L, Kang SA, Lee HO, et al. Relationships between dietary intake and cognitive function level in Korean elderly people. Public Health. 2001;115(2):133-138. [pmid: 11406779].
94 Renvall MJ, Spindler AA, Ramsdell JW, Paskvan M. Nutritional status of free-living Alzheimer's patients. Am J Med Sci. 1989;298(1):20-27. [pmid: 2750771].
95 Requejo AM, Ortega RM, Robles F, et al. Influence of nutrition on cognitive function in a group of elderly, independently living people. Eur J Clin Nutr. 2003;57(Suppl 1):S54-S57. [pmid: 12947454].
96 Tucker KL, Qiao N, Scott T, Rosenberg I, Spiro A III. High homocysteine and low B vitamins predict cognitive decline in aging men: the Veterans Affairs Normative Aging Study. Am J Clin Nutr. 2005;82(3):627-635. [pmid: 16155277].
97 Thompson FE, Byers T. Dietary assessment resource manual. J Nutr. 1994;124(11 Suppl):2245S-2317S. [pmid: 7965210].
98 Morris MC, Evans DA, Bienias JL, et al. Dietary folate and vitamin B12 intake and cognitive decline among community-dwelling older persons. Arch Neurol. 2005;62(4):641-645. [pmid: 15824266].
99 Assantachai P, Yamwong P, Chongsuphaijaisiddhi T. Relationships of vitamin B1, B12, folate and the cognitive ability of the Thai rural elderly. J Med Assoc Thai. 1997;80(11):700-705. [pmid: 9385766].
100 Gold M, Chen MF, Johnson K. Plasma and red blood cell thiamine deficiency in patients with dementia of the Alzheimer's type. Arch Neurol. 1995;52(11):1081-1086. [pmid: 7487560].
101 Gold M, Hauser RA, Chen MF. Plasma thiamine deficiency associated with Alzheimer's disease but not Parkinson's disease. Metab Brain Dis. 1998;13(1):43-53. [pmid: 9570639].
102 Jimenez-Jimenez FJ, Molina JA, Hernanz A, et al. Cerebrospinal fluid levels of thiamine in patients with Parkinson's disease. Neurosci Lett. 1999;271(1):33-36. [pmid: 10471207].
103 Mastrogiacoma F, Bettendorff L, Grisar T, Kish SJ. Brain thiamine, its phosphate esters, and its metabolizing enzymes in Alzheimer's disease. Ann Neurol. 1996;39(5):585-591. [pmid: 8619543].
104 Molina JA, Jimenez-Jimenez FJ, Hernanz A, et al. Cerebrospinal fluid levels of thiamine in patients with Alzheimer's disease. J Neural Transm. 2002;109(78):1035-1044. [pmid: 12111441].
105 Snowdon DA, Tully CL, Smith CD, Riley KP, Markesbery WR. Serum folate and the severity of atrophy of the neocortex in Alzheimer disease: findings from the Nun study. Am J Clin Nutr. 2000;71(4):993-998. [pmid: 10731508].
106 Scileppi KP, Blass JP, Baker HG. Circulating vitamins in Alzheimer's dementia as compared with other dementias. J Am Geriatr Soc. 1984;32(10):709-711. [pmid: 6481049].
107 Coimbra CG, Junqueira VB. High doses of riboflavin and the elimination of dietary red meat promote the recovery of some motor functions in Parkinson's disease patients. Braz J Med Biol Res. 2003;36(10):1409-1417. [pmid: 14502375].
108 Malaguarnera M, Ferri R, Bella R, et al. Homocysteine, vitamin B12 and folate in vascular dementia and in Alzheimer disease. Clin Chem Lab Med. 2004;42(9):1032-1035. [pmid: 15497469].
109 Miller JW, Green R, Mungas DM, Reed BR, Jagust WJ. Homocysteine, vitamin B6, and vascular disease in AD patients. Neurology. 2002;58(10):1471-1475. [pmid: 12034781].
110 Ravaglia G, Forti P, Maioli F, et al. Elevated plasma homocysteine levels in centenarians are not associated with cognitive impairment. Mech Ageing Dev. 2000;121(13):251-261. [pmid: 11164478].
111 Woitalla D, Kuhn W, Muller T. MTHFR C677T polymorphism, folic acid and hyperhomocysteinemia in levodopa treated patients with Parkinson's disease. J Neural Transm Suppl 2004;(68):15–20.
112 Kado DM, Karlamangla AS, Huang MH, et al. Homocysteine versus the vitamins folate, B6, and B12 as predictors of cognitive function and decline in older high-functioning adults: MacArthur Studies of Successful Aging. Am J Med. 2005;118(2):161-167. [pmid: 15694902].
113 Bowirrat A, Friedland RP, Farrer L, Baldwin C, Korczyn A. Genetic and environmental risk factors for Alzheimer's disease in Israeli Arabs. J Mol Neurosci. 2002;19(12):239-245. [pmid: 12212789].
114 Elias MF, Sullivan LM, D'Agostino RB, et al. Homocysteine and cognitive performance in the framingham offspring study: age is important. Am J Epidemiol. 2005;162(7):644-653. [pmid: 16107567].
115 Ravaglia G, Forti P, Maioli F, et al. Homocysteine and folate as risk factors for dementia and Alzheimer disease. Am J Clin Nutr. 2005;82(3):636-643. [pmid: 16155278].
116 Engelborghs S, Vloeberghs E, Maertens K, et al. Correlations between cognitive, behavioural and psychological findings and levels of vitamin B12 and folate in patients with dementia. Int J Geriatr Psychiatry. 2004;19(4):365-370. [pmid: 15065230].
117 Stuerenburg HJ, MuellerThomsen T, Methner A. Vitamin B 12 plasma concentrations in Alzheimer disease. Neuroendocrinol Lett. 2004;25(3):176-177. [pmid: 15349081].
118 Whyte EM, Mulsant BH, Butters MA, et al. Cognitive and behavioral correlates of low vitamin B12 levels in elderly patients with progressive dementia. Am J Geriatr Psychiatry. 2002;10(3):321-327. [pmid: 11994220].
119 Andersen-Ranberg K, Vasegaard L, Jeune B. Dementia is not inevitable: a population-based study of Danish centenarians. J Gerontol B Psychol Sci Soc Sci. 2001;56(3):P152-159. [pmid: 11316833].
120 Anello G, Gueant-Rodriguez RM, Bosco P, et al. Homocysteine and methylenetetrahydrofolate reductase polymorphism in Alzheimer's disease. Neuroreport. 2004;15(5):859-861. [pmid: 15073531].
121 Argyriadou S, Vlachonikolis I, Melisopoulou H, Katachanakis K, Lionis C. In what extent anemia coexists with cognitive impairment in elderly: a cross-sectional study in Greece. BMC Fam Pract. 2001;2(1):5. [pmid: 11707152]. [pmcid: 59691].
122 Cacabelos R, Fernandez-Novoa L, Corzo L, et al. Genomics and phenotypic profiles in dementia: implications for pharmacological treatment. Methods Find Exp Clin Pharmacol. 2004;26(6):421-444. [pmid: 15349138].
123 Clarke R, Smith AD, Jobst KA, et al. Folate, vitamin B12, and serum total homocysteine levels in confirmed Alzheimer disease. Arch Neurol. 1998;55(11):1449-1455. [pmid: 9823829].
124 Gottfries J, Blennow K, Lehmann MW, Regland B, Gottfries CG. One-carbon metabolism and other biochemical correlates of cognitive impairment as visualized by principal component analysis. J Geriatr Psychiatry Neurol. 2001;14(3):109-114. [pmid: 11563432].
125 Joosten E, Lesaffre E, Riezler R, et al. Is metabolic evidence for vitamin B-12 and folate deficiency more frequent in elderly patients with Alzheimer's disease?. J Gerontol A Biol Sci Med Sci. 1997;52(2):M76-M79. [pmid: 9060973].
126 McCaddon A, Blennow K, Hudson P, et al. Transcobalamin polymorphism and serum holo-transcobalamin in relation to Alzheimer's disease. Dement Geriatr Cogn Disord. 2004;71(3):215-221.
127 Mizrahi EH, Bowirrat A, Jacobsen DW, et al. Plasma homocysteine, vitamin B12 and folate in Alzheimer's patients and healthy Arabs in Israel. J Neurol Sci. 2004;227(1):109-113. [pmid: 15546600].
128 Nilsson K, Gustafson L, Faldt R, et al. Hyperhomocysteinaemia—a common finding in a psychogeriatric population. Eur J Clin Invest. 1996;26(10):853-859. [pmid: 8911857].
129 Postiglione A, Milan G, Ruocco A, et al. Plasma folate, vitamin B(12), and total homocysteine and homozygosity for the C677T mutation of the 5,10-methylene tetrahydrofolate reductase gene in patients with Alzheimer's dementia. A case-control study. Gerontology. 2001;47(6):324-329. [pmid: 11721146].
130 Quadri P, Fragiacomo C, Pezzati R, et al. Homocysteine, folate, and vitamin B-12 in mild cognitive impairment, Alzheimer disease, and vascular dementia. Am J Clin Nutr. 2004;80(1):114-122. [pmid: 15213037].
131 Ravaglia G, Forti P, Maioli F, et al. Homocysteine and cognitive function in healthy elderly community dwellers in Italy. Am J Clin Nutr. 2003;77(3):668-673. [pmid: 12600859].
132 Religa D, Styczynska M, Peplonska B, et al. Homocysteine, apolipoproteine E and methylenetetrahydrofolate reductase in Alzheimer's disease and mild cognitive impairment. Dement Geriatr Cogn Disord. 2003;16(2):64-70. [pmid: 12784029].
133 Shahar A, Feiglin L, Shahar DR, Levy S, Seligsohn U. High prevalence and impact of subnormal serum vitamin B12 levels in Israeli elders admitted to a geriatric hospital. J Nutr Health Aging. 2001;5(2):124-127. [pmid: 11426294].
134 Tripathi M, Sheshadri S, Padma MV, et al. Serum cobalamin levels in dementias. Neurol India. 2001;49(3):284-286. [pmid: 11593247].
135 Regland B, Gottfries CG, Oreland L, Svennerholm L. Low B12 levels related to high activity of platelet MAO in patients with dementia disorders. A retrospective study. Acta Psychiatri Scand. 1988;78(4):451-457.
136 Refsum H, Smith AD. Low vitamin B-12 status in confirmed Alzheimer's disease as revealed by serum holotranscobalamin. J Neurol Neurosurg Psychiatry. 2003;74(7):959-961. [pmid: 12810791]. [pmcid: 1738528].
137 Nagga K, Rajani R, Mardh E, et al. Cobalamin, folate, methylmalonic acid, homocysteine, and gastritis markers in dementia. Dement Geriatr Cogn Disord. 2003;16(4):269-275. [pmid: 14512723].
138 Nilsson SE, Takkinen S, Tryding N, et al. Association of biochemical values with morbidity in the elderly: a population-based Swedish study of persons aged 82 or more years. Scand J Clin Lab Invest. 2003;63(78):457-466. [pmid: 14743954].
139 Serot JM, Christmann D, Dubost T, Bene MC, Faure GC. CSF-folate levels are decreased in late-onset AD patients. J Neural Transm. 2001;108(1):93-99. [pmid: 11261750].
140 Maxwell CJ, Hogan DB, Ebly EM. Serum folate levels and subsequent adverse cerebrovascular outcomes in elderly persons. Dement Geriatr Cogn Disord. 2002;13(4):225-234. [pmid: 12006733].
141 Stewart R, Asonganyi B, Sherwood R. Plasma homocysteine and cognitive impairment in an older British African-Caribbean population. J Am Geriatr Soc. 2002;50(7):1227-1232. [pmid: 12133017].
142 Jones S, Small BJ, Fratiglioni L, Backman L. Predictors of cognitive change from preclinical to clinical Alzheimer's disease. Brain Cogn. 2002;49(2):210-213. [pmid: 15259392].
143 Selhub J, Jacques PF, Wilson PWF, Rush D, Rosenberg IH. Vitamin status and intake as primary determinants of homocysteinemia in an elderly population. JAMA. 1993;270(22):2693-2698. [pmid: 8133587].
144 Selhub J, Bagley LC, Miller J, Rosenberg IH. B vitamins, homocysteine, and neurocognitive function in the elderly. Am J Clin Nutr. 2000;71(2):614S-620S. [pmid: 10681269].
145 Smith AD. Homocysteine, B vitamins, and cognitive deficit in the elderly. Am J Clin Nutr. 2002;75:785-786. [pmid: 11976150].
146 Garcia A, Zanibbi K. Homocysteine and cognitive function in elderly people. Can Med Assoc J. 2004;171(8):897-904. [pmid: 15477631]. [pmcid: 522658].
147 Morris MS, Jacques PF, Rosenberg IH, Selhub J, National Health and Nutrition Examination Survey. Hyperhomocysteinemia associated with poor recall in the third National Health and Nutrition Examination Survey. Am J Clin Nutr 2001; 73(5):927–933
148 Yukawa M, Naka H, Murata Y, et al. Folic acid-responsive neurological diseases in Japan. J Nutr Sci Vitaminol (Tokyo). 2001;47(3):181-187. [pmid: 11575572].
149 Vermeulen EGJ, Stehouwer CDA, Valk J, et al. Effect of homocysteine-lowering treatment with folic acid plus vitamin B6 on cerebrovascular atherosclerosis and white matter abnormalities as determined by MRA and MRI: a placebo-controlled, randomized trial. Eur J Clin Invest. 2004;34(4):256-261. [pmid: 15086356].
150 Marks J. The safety of the vitamins: an overview. Int J Vitam Nutr Res Suppl. 1989;30:12-20. [pmid: 2507691].
151 Snodgrass SR. Vitamin neurotoxicity. Mol Neurobiol. 1992;6(1):41-73. [pmid: 1463588].
152 Wrenn KD, Murphy F, Slovis CM. A toxicity study of parenteral thiamine hydrochloride. Ann Emerg Med. 1989;18(8):167-170.
153 Cohen M, Bendich A. Safety of pyridoxine—a review of human and animal studies. Toxicol Lett. 1986;34(23):129-139. [pmid: 3541289].
154 Duvoisin RC, Yahr MD, Cote LD. Pyridoxine reversal of L-dopa effects in Parkinsonism. Trans Am Neurol Assoc. 1969;94:81-84. [pmid: 5374494].
155 Fahn S. “On-off” phenomenon with levodopa therapy in Parkinsonism. Clinical and pharmacologic correlations and the effect of intramuscular pyridoxine. Neurology. 1974;24(5):431-441. [pmid: 4857104].
156 Hsu TH, Bianchine JR, Preziosi TJ, Messiha FS. Effect of pyridoxine on levodopa metabolism in normal and parkinsonian subjects. Proc Soc Exp Biol Med. 1973;143(2):578-581. [pmid: 4709027].
157 Leon AS, Spiegel HE, Thomas G, Abrams WB. Pyridoxine antagonism of levodopa in parkinsonism. JAMA. 1971;218(13):1924-1927. [pmid: 5171069].
158 Mars H. Metabolic interactions of pyridoxine, levodopa, and carbidopa in Parkinson's disease. Trans Am Neurol Assoc. 1973;98:241-245. [pmid: 4784941].
159 Mars H. Levodopa, carbidopa, and pyridoxine in Parkinson disease. Metabolic interactions. Arch Neurol. 1974;30(6):444-447. [pmid: 4827061].
160 Bhagavan HN, Brin M. Drug—vitamin B6 interaction. Curr Concepts Nutr. 1983;12:1-12.
161 Campbell NR. How safe are folic acid supplements?. Arch Intern Med. 1996;156(15):1638-1644. [pmid: 8694661].
162 Hathcock JN. Vitamins and minerals: efficacy and safety. Am J Clin Nutr. 1997;66(2):427-437. [pmid: 9250127].
163 U.S. Department of Agriculture. USDA Database for the Flavonoid Content of Selected Foods. 3-25-2003. Beltsville, Maryland 20705, USDA Agricultural Research Service, Beltsville Human Nutrition Research Center, Nutrient Data Laboratory.
164 Moyer RA, Hummer KE, Finn CE, Frei B, Wrolstad RE. Anthocyanins, phenolics, and antioxidant capacity in diverse small fruits: vaccinium, rubus, and ribes. J Agric Food Chem. 2002;50(3):519-525. [pmid: 11804523].
165 Siriwoharn T, Wrolstad RE, Finn CE, Pereira CB. Influence of cultivar, maturity, and sampling on blackberry (Rubus L. Hybrids) anthocyanins, polyphenolics, and antioxidant properties. J Agric Food Chem. 2004;52(26):8021-8030. [pmid: 15612791].
166 Prior RL, Hoang H, Gu L, et al. Assays for hydrophilic and lipophilic antioxidant capacity (oxygen radical absorbance capacity (ORAC(FL))) of plasma and other biological and food samples. J Agric Food Chem. 2003;51(11):3273-3279. [pmid: 12744654].
167 Halvorsen BL, Holte K, Myhrstad MC, et al. A systematic screening of total antioxidants in dietary plants. J Nutr. 2002;132(3):461-471. [pmid: 11880572].
168 Wu X, Beecher GR, Holden JM, et al. Lipophilic and hydrophilic antioxidant capacities of common foods in the United States. J Agric Food Chem. 2004;52(12):4026-4037. [pmid: 15186133].
169 Saija A, Princi P, D'Amico N, De Pasquale R, Costa G. Effect of Vaccinium myrtillus anthocyanins on triiodothyronine transport into brain in the rat. Pharmacol Res. 1990;22(Suppl 3):59-60.
170 Shukitt-Hale B, Galle E, Methner A, Carey A, Bielinski D. Dietary supplementation with fruit polyphenolics ameliorates age-related deficits in behavior and neuronal markers of inflammation and oxidative stress. Age. 2005;27:49-57.
171 Wang BH, Foo LY, Polya GM. Differential inhibition of eukaryote protein kinases by condensed tannins. Phytochemistry. 1996;43(2):359-365. [pmid: 8862029].
172 Andres-Lacueva C, Shukitt-Hale B, Galli RL, et al. Anthocyanins in aged blueberry-fed rats are found centrally and may enhance memory. Nutr Neurosci. 2005;8(2):111-120. [pmid: 16053243].
173 Bickford PC, Shukitt-Hale B, Joseph J. Effects of aging on cerebellar noradrenergic function and motor learning: nutritional interventions. Mech Ageing Dev. 1999;111(23):141-154. [pmid: 10656533].
174 Bickford PC, Gould T, Briederick L, et al. Antioxidant-rich diets improve cerebellar physiology and motor learning in aged rats. Brain Res. 2000;866(12):211-217. [pmid: 10825496].
175 Casadesus G, Shukitt-Hale B, Stellwagen HM, et al. Modulation of hippocampal plasticity and cognitive behavior by short-term blueberry supplementation in aged rats. Nutr Neurosci. 2004;7(56):309-316. [pmid: 15682927].
176 Goyarzu P, Malin DH, Lau FC, et al. Blueberry supplemented diet: effects on object recognition memory and nuclear factor-kappa B levels in aged rats. Nutr Neurosci. 2004;7(2):75-83. [pmid: 15279493].
177 Joseph JA, Denisova N, Fisher D, et al. Membrane and receptor modifications of oxidative stress vulnerability in aging. Nutritional considerations. Ann N Y Acad Sci. 1998;854:268-276. [pmid: 9928436].
178 Joseph JA, Shukitt-Hale B, Denisova NA, et al. Long-term dietary strawberry, spinach, or vitamin E supplementation retards the onset of age-related neuronal signal-transduction and cognitive behavioral deficits. J Neurosci. 1998;18(19):8047-8055. [pmid: 9742171].
179 Joseph JA, Shukitt-Hale B, Denisova NA, et al. Reversals of age-related declines in neuronal signal transduction, cognitive, and motor behavioral deficits with blueberry, spinach, or strawberry dietary supplementation. J Neurosci. 1999;19(18):8114-8121. [pmid: 10479711].
180 Joseph JA, Denisova NA, Arendash G, et al. Blueberry supplementation enhances signaling and prevents behavioral deficits in an Alzheimer disease model. Nutr Neurosci. 2003;6(3):153-162. [pmid: 12793519].
181 Joseph JA, Fisher DR, Carey AN. Fruit extracts antagonize Abeta- or DA-induced deficits in Ca2+ flux in M1-transfected COS-7 cells. J Alzheimers Dis. 2004;6(4):403-411. [pmid: 15345811].
182 Martin A, Prior R, Shukitt-Hale B, Cao G, Joseph JA. Effect of fruits, vegetables, or vitamin E—rich diet on vitamins E and C distribution in peripheral and brain tissues: implications for brain function. J Gerontol A Biol Sci Med Sci. 2000;55(3):B144-B151. [pmid: 10795718].
183 Rabin BM, Joseph JA, Shukitt-Hale B. Effects of age and diet on the heavy particle-induced disruption of operant responding produced by a ground-based model for exposure to cosmic rays. Brain Res. 2005;1036(12):122-129. [pmid: 15725409].
184 Rabin BM, Carrihill-Knoll K, Carey A, Shukitt-Hale B. Effect of diet on the disruption of operant responding at different ages following exposure to 56Fe particles. Age. 2005;27:69-73.
185 Shukitt-Hale B, Smith DE, Meydani M, Joseph JA. The effects of dietary antioxidants on psychomotor performance in aged mice. Expl Gerontol. 1999;34(6):797-808.
186 Youdim KA, Shukitt-Hale B, Martin A, et al. Short-term dietary supplementation of blueberry polyphenolics: Beneficial effects on aging brain performance and peripheral tissue function. Nutr Neuroscience. 2000;3:383-397.
187 Lindner MD. Reliability, distribution, and validity of age-related cognitive deficits in the Morris water maze. Neurobiol Learn Mem. 1997;68(3):203-220. [pmid: 9398584].
188 Golbe LI, Farrell TM, Davis PH. Case-control study of early life dietary factors in Parkinson's disease. Arch Neurol. 1988;45(12):1350-1353. [pmid: 3196195].
189 Canter PH, Ernst E. Anthocyanosides of Vaccinium myrtillus (bilberry) for night vision—a systematic review of placebo-controlled trials. Surv Ophthalmol. 2004;49(1):38-50. [pmid: 14711439].
190 Morazzoni P, Bombardelli E. Vaccinium myrtillus L. Fitoterapia. 1996;67(1):3-29.
191 Leventhal LJ, Boyce EG, Zurier RB. Treatment of rheumatoid arthritis with blackcurrant seed oil. Br J Rheumatol. 1994;33(9):847-852. [pmid: 8081671].
192 Suvarna R, Pirmohamed M, Henderson L. Possible interaction between warfarin and cranberry juice. BMJ. 2003;327(7429):1454. [pmid: 14684645]. [pmcid: 300803].
193 Steckler T, Muir JL. Measurement of cognitive function: relating rodent performance with human minds. Brain Res Cogn Brain Res. 1996;3(34):299-308. [pmid: 8806031].
194 D'Mello GD, Steckler T. Animal models in cognitive behavioural pharmacology: an overview. Brain Res Cogn Brain Res. 1996;3(34):345-352. [pmid: 8806035].
195 Moher D, Schulz KF, Altman DG. CONSORT group. The CONSORT Statement: Revised Recommendations for Improving the Quality of Reports of Parallel-Group Randomized Trials. Ann Intern Med. 2001;134(8):657-662. [pmid: 11304106].
196 Altman DG, Schulz KF, Moher D, et al. The Revised CONSORT Statement for Reporting Randomized Trials: Explanation and Elaboration. Ann Intern Med. 2001;134(8):663-694. [pmid: 11304107].
197 van der Staay FJ. Assessment of age-associated cognitive deficits in rats: a tricky business. Neurosci Biobehav Rev. 2002;26(7):753-759. [pmid: 12470686].

### Bibliography

B Vitamins - Animal / In Vitro Studies

Ciccia RM, Langlais PJ. An examination of the synergistic interaction of ethanol and thiamine deficiency in the development of neurological signs and long-term cognitive and memory impairments. Alcohol Clin Exp Res. 2000;24(5):622-634. [pmid: 10832903].
Driskell JA, Strickland LA, Poon CH, Foshee DP. The vitamin B6 requirement of the male rat as determined by behavioral patterns, brain pyridoxal phosphate and nucleic acid composition and erythrocyte alanine aminotransferase activity. J Nutr. 1973;103(5):670-680. [pmid: 4710079].
Duan W, Ladenheim B, Cutler RG, et al. Dietary folate deficiency and elevated homocysteine levels endanger dopaminergic neurons in models of Parkinson's disease. J Neurochem. 2002;80(1):101-110. [pmid: 11796748].
Fuso A, Seminara L, Cavallaro RA, D'Anselmi F, Scarpa S. S-adenosylmethionine/homocysteine cycle alterations modify DNA methylation status with consequent deregulation of PS1 and BACE and beta-amyloid production. Mol Cell Neurosci. 2005;28(1):195-204. [pmid: 15607954].
Jolicoeur FB, Rondeau DB, Barbeau A, Wayner MJ. Comparison of neurobehavioral effects induced by various experimental models of ataxia in the rat. Neurobehav Toxicol. 1979;1(S1):175-178. [pmid: 299576].
Jolicoeur FB, Rondeau DB, Hamel E, Butterworth RF, Barbeau A. Measurement of ataxia and related neurological signs in the laboratory rat. Can J Neurol Sci. 1979;6(2):209-215. [pmid: 487313].
Kim JM, Lee H, Chang N. Hyperhomocysteinemia due to short-term folate deprivation is related to electron microscopic changes in the rat brain. J Nutr. 2002;132(11):3418-3421. [pmid: 12421861].
Kruman II, Kumaravel TS, Lohani A, et al. Folic acid deficiency and homocysteine impair DNA repair in hippocampal neurons and sensitize them to amyloid toxicity in experimental models of Alzheimer's disease. J Neurosci. 2002;22(5):1752-1762. [pmid: 11880504].
Lee H, Kim HJ, Kim JM, Chang N. Effects of dietary folic acid supplementation on cerebrovascular endothelial dysfunction in rats with induced hyperhomocysteinemia. Brain Res. 2004;996(2):139-147. [pmid: 14697491].
Lee H, Kim JM, Kim HJ, Lee I, Chang N. Folic acid supplementation can reduce the endothelial damage in rat brain microvasculature due to hyperhomocysteinemia. J Nutr. 2005;135(3):544-548. [pmid: 15735091].
Manz HJ, Robertson DM. Vascular permeability to horseradish peroxidase in brainstem lesions of thiamine-deficient rats. Am J Pathol. 1972;66(3):565-576. [pmid: 5060583]. [pmcid: 2032735].
Masuda Y, Kokubu T, Yamashita M, Ikeda H, Inoue S. EGG phosphatidylcholine combined with vitamin B12 improved memory impairment following lesioning of nucleus basalis in rats. Life Sci. 1998;62(9):813-822. [pmid: 9496699].
Mattson MP, Chan SL, Duan W. Modification of brain aging and neurodegenerative disorders by genes, diet, and behavior. Physiol Rev. 2002;82(3):637-672. [pmid: 12087131].
Robertson DM, Manz HJ. Effect of thiamine deficiency on the competence of the blood-brain barrier to albumin labeled with fluorescent dyes. Am J Pathol. 1971;63(3):393-402. [pmid: 5581230]. [pmcid: 2047487].
Shea TB, Rogers E. Folate quenches oxidative damage in brains of apolipoprotein E-deficient mice: augmentation by vitamin E. Brain Res Mol Brain Res. 2002;108(12):1-6. [pmid: 12480173].
Shea TB, Rogers E, Ashline D, et al. Vitamin E deficiency does not induce compensatory antioxidant increases in central nervous system tissue of apolipoprotein E-deficient mice. J Alzheimers Dis. 2003;5(1):9-14. [pmid: 12590161].
Shea TB, Rogers E, Ashline D, Ortiz D, Sheu MS. Apolipoprotein E deficiency promotes increased oxidative stress and compensatory increases in antioxidants in brain tissue. Free Radic Biol Med. 2002;33(8):1115-1120. [pmid: 12374623].
Terasawa M, Nakahara T, Tsukada N, Sugawara A, Itokawa Y. The relationship between thiamine deficiency and performance of a learning task in rats. Metabol Brain Dis. 1999;14(3):137-148.
Tunnicliff G, Wimer RE, Roberts E. Pyridoxine dietary levels and open-field activity of inbred mice. Brain Res. 1972;42(1):234-238. [pmid: 5047194].
Warnock LG, Burkhalter VJ. Evidence of malfunctioning blood-brain barrier in experimental thiamine deficiency in rats. J Nutr. 1968;94(2):256-260. [pmid: 5637221].
Zimitat C, Kril J, Harper CG, Nixon PF. Progression of neurological disease in thiamin-deficient rats is enhanced by ethanol. Alcohol. 1990;7(6):493-501. [pmid: 2261086].

B Vitamins - Human Studies

Abyad A. Prevalence of vitamin B12 deficiency among demented patients and cognitive recovery with cobalamin replacement. J Nutr Health Aging. 2002;6(4):254-260. [pmid: 12486445].
Aisen PS, Egelko S, Andrews H, et al. A pilot study of vitamins to lower plasma homocysteine levels in Alzheimer disease. Am J Geriatr Psychiatry. 2003;11(2):246-249. [pmid: 12611755].
Andersen-Ranberg K, Vasegaard L, Jeune B. Dementia is not inevitable: a population-based study of Danish centenarians. J Gerontol B Psychol Sci Soc Sci. 2001;56(3):P152-159. [pmid: 11316833].
Anello G, Gueant-Rodriguez RM, Bosco P, et al. Homocysteine and methylenetetrahydrofolate reductase polymorphism in Alzheimer's disease. Neuroreport. 2004;15(5):859-861. [pmid: 15073531].
Argyriadou S, Vlachonikolis I, Melisopoulou H, Katachanakis K, Lionis C. In what extent anemia coexists with cognitive impairment in elderly: a cross-sectional study in Greece. BMC Fam Pract. 2001;2(1):5. [pmid: 11707152]. [pmcid: 59691].
Assantachai P, Yamwong P, Chongsuphaijaisiddhi T. Relationships of vitamin B1, B12, folate and the cognitive ability of the Thai rural elderly. J Med Assoc Thai. 1997;80(11):700-705. [pmid: 9385766].
Blass JP, Gleason P, Brush D, DiPonte P, Thaler H. Thiamine and Alzheimer's disease. A pilot study. Arch Neurol. 1988;45(8):833-835. [pmid: 2969232].
Bowirrat A, Friedland RP, Farrer L, Baldwin C, Korczyn A. Genetic and environmental risk factors for Alzheimer's disease in Israeli Arabs. J Mol Neurosci. 2002;19(12):239-245. [pmid: 12212789].
Bryan J, Calvaresi E, Hughes D. Short-term folate, vitamin B-12 or vitamin B-6 supplementation slightly affects memory performance but not mood in women of various ages. J Nutr. 2002;132(6):1345-1356. [pmid: 12042457].
Cacabelos R, Fernandez-Novoa L, Corzo L, et al. Genomics and phenotypic profiles in dementia: implications for pharmacological treatment. Methods Find Exp Clin Pharmacol. 2004;26(6):421-444. [pmid: 15349138].
Carmel R, Gott PS, Waters CH, et al. The frequently low cobalamin levels in dementia usually signify treatable metabolic, neurologic and electrophysiologic abnormalities. Eur J Haematology. 1995;54(4):245-253.
Chen H, Zhang SM, Schwarzschild MA, et al. Folate intake and risk of Parkinson's disease. Am J Epidemiol. 2004;160(4):368-375. [pmid: 15286022].
Clarke R, Harrison G, Richards S. Vital Trial Collaborative Group. Effect of vitamins and aspirin on markers of platelet activation, oxidative stress and homocysteine in people at high risk of dementia. J Intern Med. 2003;254(1):67-75. [pmid: 12823643].
Clarke R, Smith AD, Jobst KA, et al. Folate, vitamin B12, and serum total homocysteine levels in confirmed Alzheimer disease. Arch Neurol. 1998;55(11):1449-1455. [pmid: 9823829].
Coimbra CG, Junqueira VB. High doses of riboflavin and the elimination of dietary red meat promote the recovery of some motor functions in Parkinson's disease patients. Braz J Med Biol Res. 2003;36(10):1409-1417. [pmid: 14502375].
Deijen JB, Slump E, Wouters-Wesseling W, et al. Nutritional intake and daily functioning of psychogeriatric nursing home residents. J Nutr Health Aging. 2003;7(4):242-246. [pmid: 12917748].
Deijen JB, van der Beek EJ, Orlebeke JF, van den BH. Vitamin B-6 supplementation in elderly men: effects on mood, memory, performance and mental effort. Psychopharmacology. 1992;109(4):489-496. [pmid: 1365868].
Elias MF, Sullivan LM, D'Agostino RB, et al. Homocysteine and cognitive performance in the framingham offspring study: age is important. Am J Epidemiol. 2005;162(7):644-653. [pmid: 16107567].
Engelborghs S, Vloeberghs E, Maertens K, et al. Correlations between cognitive, behavioural and psychological findings and levels of vitamin B12 and folate in patients with dementia. Int J Geriatr Psychiatry. 2004;19(4):365-370. [pmid: 15065230].
Fioravanti M, Ferrario E, Massaia M, et al. Low folate levels in the cognitive decline of elderly patients and the efficacy of folate as a treatment for improving memory deficits. Arch Gerontol and Geriatrics. 1997;26(1):1-13.
Gold M, Chen MF, Johnson K. Plasma and red blood cell thiamine deficiency in patients with dementia of the Alzheimer's type. Arch Neurol. 1995;52(11):1081-1086. [pmid: 7487560].
Gold M, Hauser RA, Chen MF. Plasma thiamine deficiency associated with Alzheimer's disease but not Parkinson's disease. Metab Brain Dis. 1998;13(1):43-53. [pmid: 9570639].
Goodwin JS, Goodwin JM, Garry PJ. Association between nutritional status and cognitive functioning in a healthy elderly population. JAMA. 1983;249(21):2917-2921. [pmid: 6842805].
Gottfries J, Blennow K, Lehmann MW, Regland B, Gottfries CG. One-carbon metabolism and other biochemical correlates of cognitive impairment as visualized by principal component analysis. J Geriatr Psychiatry Neurol. 2001;14(3):109-114. [pmid: 11563432].
Hvas AM, Juul S, Lauritzen L, Nexo E, Ellegaard J. No effect of vitamin B-12 treatment on cognitive function and depression: a randomized placebo controlled study. J Affect Disord. 2004;81(3):269-273. [pmid: 15337331].
Ikeda T, Yamamoto K, Takahashi K, et al. Treatment of Alzheimer-type dementia with intravenous mecobalamin. Clin Ther. 1992;14(3):426-437. [pmid: 1638584].
Ito T, Yamadera H, Ito R, et al. Effects of vitamin B12 on bright light on cognitive and sleep-wake rhythm in Alzheimer-type dementia. Psychiatry Clin Neurosci. 2001;55(3):281-282. [pmid: 11422876].
Jimenez-Jimenez FJ, Molina JA, Hernanz A, et al. Cerebrospinal fluid levels of thiamine in patients with Parkinson's disease. Neurosci Lett. 1999;271(1):33-36. [pmid: 10471207].
Jones S, Small BJ, Fratiglioni L, Backman L. Predictors of cognitive change from preclinical to clinical Alzheimer's disease. Brain Cogn. 2002;49(2):210-213. [pmid: 15259392].
Joosten E, Lesaffre E, Riezler R, et al. Is metabolic evidence for vitamin B-12 and folate deficiency more frequent in elderly patients with Alzheimer's disease?. J Gerontol A Biol Sci Med Sci. 1997;52(2):M76-M79. [pmid: 9060973].
Kado DM, Karlamangla AS, Huang MH, et al. Homocysteine versus the vitamins folate, B6, and B12 as predictors of cognitive function and decline in older high-functioning adults: MacArthur Studies of Successful Aging. Am J Med. 2005;118(2):161-167. [pmid: 15694902].
Kral VA, Solyom L, Enesco H, Ledwidge B. Relationship of vitamin B12 and folic acid to memory function. Biol Psychiatry. 1970;2(1):19-26. [pmid: 5414901].
Kwok T, Tang C, Woo J, et al. Randomized trial of the effect of supplementation on the cognitive function of older people with subnormal cobalamin levels. Int J Geriatr Psychiatry. 1998;13(9):611-616. [pmid: 9777425].
Lee L, Kang SA, Lee HO, et al. Relationships between dietary intake and cognitive function level in Korean elderly people. Public Health. 2001;115(2):133-138. [pmid: 11406779].
Lehmann M, Regland B, Blennow K, Gottfries CG. Vitamin B12-B6-folate treatment improves blood-brain barrier function in patients with hyperhomocysteinaemia and mild cognitive impairment. Dement Geriatr Cogn Disord. 2003;16(3):145-150. [pmid: 12826740].
Lewerin C, Matousek M, Steen G, et al. Significant correlations of plasma homocysteine and serum methylmalonic acid with movement and cognitive performance in elderly subjects but no improvement from short-term vitamin therapy: a placebo-controlled randomized study. Am J Clin Nutr. 2005;81(5):1155-1162. [pmid: 15883442].
Malaguarnera M, Ferri R, Bella R, et al. Homocysteine, vitamin B12 and folate in vascular dementia and in Alzheimer disease. Clin Chem Lab Med. 2004;42(9):1032-1035. [pmid: 15497469].
Martin DC, Francis J, Protetch J, Huff FJ. Time dependency of cognitive recovery with cobalamin replacement: report of a pilot study. J Am Geriatr Society. 1992;40(2):168-172.
Mastrogiacoma F, Bettendorff L, Grisar T, Kish SJ. Brain thiamine, its phosphate esters, and its metabolizing enzymes in Alzheimer's disease. Ann Neurol. 1996;39(5):585-591. [pmid: 8619543].
Maxwell CJ, Hogan DB, Ebly EM. Serum folate levels and subsequent adverse cerebrovascular outcomes in elderly persons. Dement Geriatr Cogn Disord. 2002;13(4):225-234. [pmid: 12006733].
McCaddon A, Blennow K, Hudson P, et al. Transcobalamin polymorphism and serum holo-transcobalamin in relation to Alzheimer's disease. Dement Geriatr Cogn Disord. 2004;71(3):215-221.
McGeer PL, Zeldowicz L, McGeer EG. A clinical trial of folic acid in Parkinson's disease. Can Med Assoc J. 1972;106(2):145-146. [pmid: 4400558]. [pmcid: 1940357].
Meador K, Loring D, Nichols M, et al. Preliminary findings of high-dose thiamine in dementia of Alzheimer's type. J Geriatr Psychiatry Neurol. 1993;6(4):222-229. [pmid: 8251051].
Miller JW, Green R, Mungas DM, Reed BR, Jagust WJ. Homocysteine, vitamin B6, and vascular disease in AD patients. Neurology. 2002;58(10):1471-1475. [pmid: 12034781].
Mimori Y, Katsuoka H, Nakamura S. Thiamine therapy in Alzheimer's disease. Metab Brain Dis. 1996;11(1):89-94. [pmid: 8815393].
Mitsuyama Y, Kogoh H. Serum and cerebrospinal fluid vitamin B12 levels in demented patients with CH3-B12 treatment—preliminary study. Jpn J Psychiatry Neurol. 1988;42(1):65-71. [pmid: 3398357].
Mizrahi EH, Bowirrat A, Jacobsen DW, et al. Plasma homocysteine, vitamin B12 and folate in Alzheimer's patients and healthy Arabs in Israel. J Neurol Sci. 2004;227(1):109-113. [pmid: 15546600].
Mizrahi EH, Jacobsen DW, Debanne SM, et al. Plasma total homocysteine levels, dietary vitamin B6 and folate intake in AD and healthy aging. J Nutr Health Aging. 2003;7(3):160-165. [pmid: 12766793].
Molina JA, Jimenez-Jimenez FJ, Hernanz A, et al. Cerebrospinal fluid levels of thiamine in patients with Alzheimer's disease. J Neural Transm. 2002;109(12):1035-1044. [pmid: 12111441].
Morris MC, Evans DA, Bienias JL, et al. Dietary folate and vitamin B12 intake and cognitive decline among community-dwelling older persons. Arch Neurol. 2005;62(4):641-645. [pmid: 15824266].
Nagga K, Rajani R, Mardh E, et al. Cobalamin, folate, methylmalonic acid, homocysteine, and gastritis markers in dementia. Dement Geriatr Cogn Disord. 2003;16(4):269-275. [pmid: 14512723].
Nilsson K, Gustafson L, Faldt R, et al. Hyperhomocysteinaemia—a common finding in a psychogeriatric population. Eur J Clin Invest. 1996;26(10):853-859. [pmid: 8911857].
Nilsson K, Gustafson L, Hultberg B. Improvement of cognitive functions after cobalamin/folate supplementation in elderly patients with dementia and elevated plasma homocysteine. Int J Geriatr Psychiatry. 2001;16(6):609-614. [pmid: 11424170].
Nilsson SE, Takkinen S, Tryding N, et al. Association of biochemical values with morbidity in the elderly: a population-based Swedish study of persons aged 82 or more years. Scand J Clin Lab Invest. 2003;63(78):457-466. [pmid: 14743954].
Nolan KA, Black RS, Sheu KF, Langberg J, Blass JP. A trial of thiamine in Alzheimer's disease. Arch Neurol. 1991;48(1):81-83. [pmid: 1986730].
Postiglione A, Milan G, Ruocco A, et al. Plasma folate, vitamin B(12), and total homocysteine and homozygosity for the C677T mutation of the 5,10-methylene tetrahydrofolate reductase gene in patients with Alzheimer's dementia. A case-control study. Gerontology. 2001;47(6):324-329. [pmid: 11721146].
Quadri P, Fragiacomo C, Pezzati R, et al. Homocysteine, folate, and vitamin B-12 in mild cognitive impairment, Alzheimer disease, and vascular dementia. Am J Clin Nutr. 2004;80(1):114-122. [pmid: 15213037].
Rapin JR, LePoncin M, Grebyl J. Blood folates deficiencies and cognitive functions in aging. Trends Biomed Gerontol. 1988;1:315-323.
Ravaglia G, Forti P, Maioli F, et al. Homocysteine and folate as risk factors for dementia and Alzheimer disease. Am J Clin Nutr. 2005;82(3):636-643. [pmid: 16155278].
Ravaglia G, Forti P, Maioli F, et al. Homocysteine and cognitive function in healthy elderly community dwellers in Italy. Am J Clin Nutr. 2003;77(3):668-673. [pmid: 12600859].
Ravaglia G, Forti P, Maioli F, et al. Elevated plasma homocysteine levels in centenarians are not associated with cognitive impairment. Mech Ageing Dev. 2000;121(13):251-261. [pmid: 11164478].
Refsum H, Smith AD. Low vitamin B-12 status in confirmed Alzheimer's disease as revealed by serum holotranscobalamin. J Neurol Neurosurg Psychiatry. 2003;74(7):959-961. [pmid: 12810791]. [pmcid: 1738528].
Regland B, Gottfries CG, Oreland L, Svennerholm L. Low B12 levels related to high activity of platelet MAO in patients with dementia disorders. A retrospective study. Acta Psychiatri Scand. 1988;78(4):451-457.
Religa D, Styczynska M, Peplonska B, et al. Homocysteine, apolipoproteine E and methylenetetrahydrofolate reductase in Alzheimer's disease and mild cognitive impairment. Dement Geriatr Cogn Disord. 2003;16(2):64-70. [pmid: 12784029].
Renvall MJ, Spindler AA, Ramsdell JW, Paskvan M. Nutritional status of free-living Alzheimer's patients. Am J Med Sci. 1989;298(1):20-27. [pmid: 2750771].
Requejo AM, Ortega RM, Robles F, et al. Influence of nutrition on cognitive function in a group of elderly, independently living people. Eur J Clin Nutr. 2003;57(Suppl 1):S54-S57. [pmid: 12947454].
Scileppi KP, Blass JP, Baker HG. Circulating vitamins in Alzheimer's dementia as compared with other dementias. J Am Geriatr Soc. 1984;32(10):709-711. [pmid: 6481049].
Seal EC, Metz J, Flicker L, Melny J. A randomized, double-blind, placebo-controlled study of oral vitamin B12 supplementation in older patients with subnormal or borderline serum vitamin B12 concentrations. J Am Geriatr Soc. 2002;50(1):146-151. [pmid: 12028259].
Serot JM, Christmann D, Dubost T, Bene MC, Faure GC. CSF-folate levels are decreased in late-onset AD patients. J Neural Transm. 2001;108(1):93-99. [pmid: 11261750].
Seshadri S, Beiser A, Selhub J, et al. Plasma homocysteine as a risk factor for dementia and Alzheimer's disease. N Engl J Med. 2002;346(7):476-483. [pmid: 11844848].
Shahar A, Feiglin L, Shahar DR, Levy S, Seligsohn U. High prevalence and impact of subnormal serum vitamin B12 levels in Israeli elders admitted to a geriatric hospital. J Nutr Health Aging. 2001;5(2):124-127. [pmid: 11426294].
Shaw DM, Macsweeney DA, Johnson AL, et al. Folate and amine metabolites in senile dementia: a combined trial and biochemical study. Psychol Med. 1971;1(2):166-171. [pmid: 5148767].
Snowdon DA, Tully CL, Smith CD, Riley KP, Markesbery WR. Serum folate and the severity of atrophy of the neocortex in Alzheimer disease: findings from the Nun study. Am J Clin Nutr. 2000;71(4):993-998. [pmid: 10731508].
Sommer BR, Hoff AL, Costa M. Folic acid supplementation in dementia: a preliminary report. J Geriatr Psychiatry Neurol. 2003;16(3):156-159. [pmid: 12967058].
Stewart R, Asonganyi B, Sherwood R. Plasma homocysteine and cognitive impairment in an older British African-Caribbean population. J Am Geriatr Soc. 2002;50(7):1227-1232. [pmid: 12133017].
Stuerenburg HJ, MuellerThomsen T, Methner A. Vitamin B 12 plasma concentrations in Alzheimer disease. Neuroendocrinol Lett. 2004;25(3):176-177. [pmid: 15349081].
Teunisse S, Bollen AE, van Gool WA, Walstra GJ. Dementia and subnormal levels of vitamin B12: effects of replacement therapy on dementia. J Neurol. 1996;243(7):522-529. [pmid: 8836942].
Tripathi M, Sheshadri S, Padma MV, et al. Serum cobalamin levels in dementias. Neurol India. 2001;49(3):284-286. [pmid: 11593247].
Tucker KL, Qiao N, Scott T, Rosenberg I, Spiro A, III. High homocysteine and low B vitamins predict cognitive decline in aging men: the Veterans Affairs Normative Aging Study. Am J Clin Nutr. 2005;82(3):627-635. [pmid: 16155277].
van Asselt DZ, Pasman JW, van Lier HJ, et al. Cobalamin supplementation improves cognitive and cerebral function in older, cobalamin-deficient persons. J Gerontol A Biol Sci Med Sci. 2001;56(12):M775-M779. [pmid: 11723153].
Wang HX, Wahlin A, Basun H, et al. Vitamin B(12) and folate in relation to the development of Alzheimer's disease. Neurology. 2001;56(9):1188-1194. [pmid: 11342684].
Whyte EM, Mulsant BH, Butters MA, et al. Cognitive and behavioral correlates of low vitamin B12 levels in elderly patients with progressive dementia. Am J Geriatr Psychiatry. 2002;10(3):321-327. [pmid: 11994220].
Woitalla D, Kuhn W, Muller T. MTHFR C677T polymorphism, folic acid and hyperhomocysteinemia in levodopa treated patients with Parkinson's disease. J Neural Transm Suppl 2004;(68):15–20.

Berries

Andres-Lacueva C, Shukitt-Hale B, Galli RL, et al. Anthocyanins in aged blueberry-fed rats are found centrally and may enhance memory. Nutr Neurosci. 2005;8(2):111-120. [pmid: 16053243].
Bickford PC, Gould T, Briederick L, et al. Antioxidant-rich diets improve cerebellar physiology and motor learning in aged rats. Brain Res. 2000;7866(12):211-217.
Bickford PC, Shukitt-Hale B, Joseph J. Effects of aging on cerebellar noradrenergic function and motor learning: nutritional interventions. Mech Ageing Dev. 1999;111(23):141-154. [pmid: 10656533].
Casadesus G, Shukitt-Hale B, Stellwagen HM, et al. Modulation of hippocampal plasticity and cognitive behavior by short-term blueberry supplementation in aged rats. Nutr Neurosci. 2004;7(56):309-316. [pmid: 15682927].
Golbe LI, Farrell TM, Davis PH. Case-control study of early life dietary factors in Parkinson's disease. Arch Neurol. 1988;45(12):1350-1353. [pmid: 3196195].
Goyarzu P, Malin DH, Lau FC, et al. Blueberry supplemented diet: effects on object recognition memory and nuclear factor-kappa B levels in aged rats. Nutr Neurosci. 2004;7(2):75-83. [pmid: 15279493].
Joseph JA, Denisova N, Fisher D, et al. Membrane and receptor modifications of oxidative stress vulnerability in aging. Nutritional considerations. Ann N Y Acad Sci. 1998;854:268-276. [pmid: 9928436].
Joseph JA, Denisova NA, Arendash G, et al. Blueberry supplementation enhances signaling and prevents behavioral deficits in an Alzheimer disease model. Nutr Neurosci. 2003;6(3):153-162. [pmid: 12793519].
Joseph JA, Fisher DR, Carey AN. Fruit extracts antagonize Abeta- or DA-induced deficits in Ca2+ flux in M1-transfected COS-7 cells. J Alzheimers Dis. 2004;6(4):403-411. [pmid: 15345811].
Joseph JA, Shukitt-Hale B, Denisova NA, et al. Reversals of age-related declines in neuronal signal transduction, cognitive, and motor behavioral deficits with blueberry, spinach, or strawberry dietary supplementation. J Neurosci. 1999;19(18):8114-8121. [pmid: 10479711].
Joseph JA, Shukitt-Hale B, Denisova NA, et al. Long-term dietary strawberry, spinach, or vitamin E supplementation retards the onset of age-related neuronal signal-transduction and cognitive behavioral deficits. J Neurosci. 1998;18(19):8047-8055. [pmid: 9742171].
Martin A, Prior R, Shukitt-Hale B, Cao G, Joseph JA. Effect of fruits, vegetables, or vitamin E—rich diet on vitamins E and C distribution in peripheral and brain tissues: implications for brain function. J Gerontol A Biol Sci Med Sci. 2000;55(3):B144-B151. [pmid: 10795718].
Rabin BM, Carrihill-Knoll K, Carey A, Shukitt-Hale B. Effect of diet on the disruption of operant responding at different ages following exposure to 56Fe particles. Age. 2005;27:69-73.
Rabin BM, Joseph JA, Shukitt-Hale B. Effects of age and diet on the heavy particle-induced disruption of operant responding produced by a ground-based model for exposure to cosmic rays. Brain Res. 2005;1036x(56):122-129. [pmid: 15725409].
Saija A, Princi P, D'Amico N, De Pasquale R, Costa G. Effect of Vaccinium myrtillus anthocyanins on triiodothyronine transport into brain in the rat. Pharmacol Res. 1990;22(Suppl 3):59-60.
Shukitt-Hale B, Galle E, Methner A, Carey A, Bielinski D. Dietary supplementation with fruit polyphenolics ameliorates age-related deficits in behavior and neuronal markers of inflammation and oxidative stress. Age. 2005;27:49-57.
Shukitt-Hale B, Smith DE, Meydani M, Joseph JA. The effects of dietary antioxidants on psychomotor performance in aged mice. Expl Gerontol. 1999;34(6):797-808.
Wang BH, Foo LY, Polya GM. Differential inhibition of eukaryote protein kinases by condensed tannins. Phytochemistry. 1996;43(2):359-365. [pmid: 8862029].
Youdim KA, Shukitt-Hale B, Martin A, et al. Short-term dietary supplementation of blueberry polyphenolics: Beneficial effects on aging brain performance and peripheral tissue function. Nutr Neuroscience. 2000;3:383-397.