# Acknowledgments

We would like to acknowledge with appreciation the following members of the Technical Expert Panel for their advice and consultation to the Evidence-based Practice Center during preparation of this report.

- James Joseph, Ph.D.
- Associate Professor
- Gerald J. and Dorothy R. Friedman School of Nutrition Science and Policy at Tufts University
- USDA Scientist
- Neuroscience Laboratory
- Jean Mayer USDA Human Nutrition Research Center on Aging at Tufts University
- Boston, Massachusetts

- Irwin H. Rosenberg, M.D.
- Senior Scientist and Director
- Nutrition and Neurocognition Laboratory
- Jean Mayer USDA Human Nutrition Research Center on Aging at Tufts University
- Boston, Massachusetts

- Alice H. Lichtenstein, D.Sc.
- Stanley N. Gershoff Professor of Nutrition Science and Policy
- Gerald J. and Dorothy R. Friedman School of Nutrition Science and Policy at Tufts University
- Senior Scientist, Director of the Cardiovascular Nutrition Laboratory
- Jean Mayer USDA Human Nutrition Research Center on Aging at Tufts University
- Boston, Massachusetts

- Thomas B. Shea, Ph.D.
- Center for Cellular Neurobiology and Neurodegeneration Research
- Department of Biological Sciences
- University of Massachusetts
- Lowell, Massachusetts

- Richard Nahin, Ph.D., M.P.H.
- Senior Advisor for Scientific Coordination
- National Center for Complementary and Alternative Medicine
- National Institutes of Health
- Bethesda, Maryland

- Anne Thurn, Ph.D.
- Director
- Evidence-Based Review Program
- Office of Dietary Supplements
- National Institutes of Health
- Bethesda, Maryland

- Henry W. Querfurth, M.D., Ph.D.
- Associate Professor of Neurology and Neuroscience
- Tufts University School of Medicine
- Chief, Neurology Research
- Caritas St. Elizabeth's Medical Center
- Boston, Massachusetts

- Nicholi Vorsa, Ph.D.
- Research Professor
- Plant Science
- Marucci Blueberry-Cranberry Research Center Plant Science/Chatsworth
- Chatsworth, New Jersey

We would also like to acknowledge with appreciation the following person for her role as a Technical Expert Consultant to the EPC:

- Barbara Shukitt-Hale, Ph.D.
- USDA Scientist, Neuroscience Laboratory, Jean Mayer USDA Human Nutrition Research
- Center on Aging at Tufts University, Boston, Massachusetts