# Discussion

## Overview

Age-related neurocognitive disorders, primarily Alzheimer's disease (AD) and Parkinson's disease (PD), have a major impact on health and well-being among older Americans. The causes of the diseases are not yet well understood, including risk factors and associations with environmental factors. While some symptomatic treatments are available, no treatments are known to prevent, slow the progression of, or cure either AD or PD.

Separate lines of evidence have suggested that B vitamin status may be associated with risk and progression of AD and PD and that constituents of various berries may also effect progression of the diseases. This report summarizes the evidence for relationships between B vitamin status and supplementation, and separately berries, and age-related neurocognitive disorders. We summarize animal and in vitro evidence for specific putative mechanisms of actions and human studies of B vitamin supplementation or berries as treatments, of associations between dietary intake and disease, and associations between B vitamin status and disease.

We identified almost 7000 potentially relevant citations regarding B vitamins and almost 5000 potentially relevant citations regarding berries and neurocognitive disorders and function. Of these, we reviewed 85 human studies and 17 animal or in vitro studies of B vitamins and one human study and 18 animal or in vitro studies of berries. Among the human studies, the majority were cross-sectional studies that correlated B vitamin status with either cognitive function or dementia diagnosis. There were relatively few intervention studies, longitudinal dietary intake or B vitamin status association studies. The large majority of studies were of poor quality, with major deficits. The animal and in vitro studies primarily used otherwise healthy rats or mice on either vitamin-deficient or berry-supplemented diets; although several did use specific animal models for either AD or PD.

Both the human and the animal or in vitro studies were widely heterogeneous in doses used, measurement methods, definitions of dementia, cognitive function tests, and/or experimental design.

## Main Findings

### B Vitamins

This report includes evaluations of vitamins B1 (thiamine), B2 (riboflavin), B6 (pyridoxine and related compounds), B12 (cobalamin), and folate.

Mechanisms of Action. All studies were performed in animal or in vitro models. We specifically included studies of neurocognitive function, movement disorders, brain neurotransmitters, brain histopathology, expression or function of AD-related genes, and blood brain barrier (BBB) or cerebrovascular endothelial function. We excluded studies that used B vitamin antagonists.

In rat studies, thiamine depleted diets result in significantly damaged brain tissue with serious neurological pathology resulting in death. Thiamine deficiency also significantly impaired performances in several neurocognitive tests.

No study examined the effects of riboflavin (B2) on outcomes of interest.

No significant effects of B6 supplementation were found for rats learning or cognitive function, although there were some beneficial effects on motor function and behaviors. These effects, though, were not consistent across the studies and did not show a dose-response relationship.

One study showed that low dose (1 mg per kg diet) vitamin B12 supplementation alone had no significant effect on spontaneous movements and did not improve memory in rats with nucleus basalis magnocellularis lesions.

In normal animal models, there were no apparent pathologic changes in brain tissue after folate deprivation, although there was a degenerative appearance of the cerebrocortical microvascular wall. One study found that folate was protective against a sub-toxic dose of 1-methyl-4-phenyl-1,2,3,6-tetrahydropyridine (MPTP), which otherwise causes profound motor dysfunction similar to PD. Using the AD model of amyloid precursor protein (APP) mutant mice folate deficiency renders hippocampal CA3 neurons in APP mutant mice vulnerable to death by a mechanism that does not involve increased amyloid β-peptide production or deposition.

Only two studies examined the effects of B vitamins on the expression or function of AD-related genes. The series of animal experiments showed that while apolipoprotein E (ApoE)-deficient mice are less capable of buffering oxidative challenge in the central nervous system than are normal mice, the genetic deficiency could be alleviated with folate repletion. The results from the in vitro study demonstrated that presenilin-1 could be induced by folate and vitamin B12 deprivation. The other genes involved in APP processing and APP itself seemed to be independent of folate and vitamin B12 deprivation.

A study found that selective transport of pyruvate across the BBB was not functioning in a normal fashion in thiamine-deficient rats; BBB damage seen in later stages corresponded to damage seen from cold-injury edema and other models of cerebral edema. The leakage across the BBB appears to be predominantly through the mechanism of pinocytosis (introduction of fluids into a cell by invagination of the cell membrane, followed by formation of vesicles within the cells), not disruption of interendothelial junctions. Another study showed that folate is protective against homocysteine-induced cerebrovascular damage.

Overall, research has shown that there were negative effects of thiamine and folate deficiency or deprivation on animals' clinical status and/or histopathology, although not all deficient animals had worse performance in neurocognitive tests. Studies have found some positive effects of the supplementations of B6, B12, and folate on animal's performance in neurocognitive tests, but studies did not show a dose-response relationship. Only folate deficiency was examined in animal models of AD or PD, and the results showed a synergistic effect with PD or AD pathology. Folate appears to protect against oxidative damage associated with ApoE deficiency. Folate and B12 deficiency also induce presenilin-1, but do not appear to affect APP. Thiamine (vitamin B1) is required for active transport of pyruvate across the BBB and maintaining integrity and normal permeability of BBB and folate is protective against homocysteine-induced cerebrovascular damage.

#### B Vitamin Intervention Trials

Vitamin B1. Five studies - three randomized controlled trials (RCTs), one non-randomized comparative trial (N-RCT), and one uncontrolled cohort study - on the effect of thiamine intervention among people with either probable or possible AD were heterogeneous in their outcomes. Most found improvements in cognitive function or a slowed rate of deterioration using some measures of cognitive testing, either compared to control or in uncontrolled studies. However, either no difference between treatment and control or no improvement with thiamine was found in all studies with other measures of cognitive function. Only the uncontrolled cohort study reported blood levels of thiamine before intervention and after intervention, and the study included AD subjects with normal mean levels of thiamine.

Vitamin B2. No prospective trial has evaluated the effect of B2 treatment on neurocognitive function.

Vitamin B6. Only two RCTs of cognitively intact populations investigated the effect of B6 intervention on cognitive function. Participants had B6 levels within normal range in both trials. With treatment, a significant improvement was found with one cognitive function test. It is also unclear whether the changes with treatment were significantly different than changes in the control arm. No other significant change was reported in the studies.

Vitamin B12. Five RCTs, one non-randomized comparative trial, and seven cohort studies assessed the effect of B12 intervention on cognitive function in humans. Two RCTs, one non-randomized comparative trial, and four cohort studies recruited participants with low B12 levels, while the rest of the studies assessed individuals with normal B12 levels. There was a large degree of heterogeneity in populations, levels of B12 deficiency, dose, route of administration, and cognitive function assessment instruments. Although several of the studies showed some improvement in cognitive function, few reached statistical significance. Among studies that assessed similar populations after implementing the same tests, results were frequently conflicting. Several cohort studies revealed significant improvement while fewer cohorts reported a significant decline in scores for cognitive function. However, the interpretation of these studies is difficult because they analyzed subjects with variable courses of dementia over time, without comparing to control groups. Vitamin B12 was given intramuscularly in the only RCT that found a significant effect in the treatment group compared with the controls. Similarly, only cohort studies that used intravenous or intramuscular vitamin B12 reported a significant effect on cognitive function scores. However, given the lack of data directly comparing oral and injected routes of vitamin B12 and the paucity of controlled trials limits any conclusions regarding the utility of different routes of administration. Some indirect evidence showed that demented or cognitively impaired patients with short duration of treatment for dementia or short disease duration might benefit more than patients with treatment or disease of longer duration if they use B12.

Folate. Five studies (three RCTs and two uncontrolled cohort studies) reported data on the effect of folate intervention among normal people or those with dementia, cognitive impairment, or PD. One RCT among subjects with dementia and normal folate levels found worse neuropsychological scores in the folate treatment group among subjects with dementia. Two other studies - one RCT and one uncontrolled cohort study - found statistically significant improvement in the folate treatment compared with placebo group among demented, cognitive impaired, and normal subjects. The study of patients with PD found no therapeutic benefit. Three studies reported blood folate levels before intervention; of which only two studies (one RCT and one uncontrolled cohort study) included patients with low folate levels.

Combination of B vitamins. Six studies (three RCTs and three uncontrolled cohort studies) assessed the effects of a combination of B vitamins as interventions on cognitive function. All used different daily doses of various B vitamins including folate, B6, and B12. Five of the six studies found no significant change in cognitive function after combination B vitamin supplementation. Only one of the uncontrolled cohort studies found a significant, large benefit. Only one RCT assessed the effects of combined vitamin intervention on patients with low blood folate levels; other studies included patients with normal mean blood vitamin levels.

Overall. There is weak evidence of a possible benefit of thiamine supplementation in people with AD. There is also weak, and inconsistent, evidence that treatment with injected vitamin B12 is of benefit among those with recent diagnoses of AD or cognitive impairment, particularly if low B12 levels have been documented. The effect of treatment with both B6 and folate is unclear. A single study of B6 found possible improvement with treatment. While studies of folate treatment among demented, cognitive impaired, and normal subjects did find an improvement in cognitive function with folate, one study of patients with dementia did find a worsening on neuropsychological testing with folate compared to controls. Combination treatments with folate, B6, and oral B12 overall were of no benefit. A single study found no benefit of folate treatment for PD. No studies evaluated vitamin B2.

B Vitamin Dietary Intake Studies. Five longitudinal studies and five cross-sectional studies examined the association between the dietary intake levels of B vitamins and cognitive function or the risk of age-related neurodegenerative diseases. No significant associations were found between dietary intakes of B6 or B12 and PD, AD, cognitive functioning, or cognitive decline across three studies. One additional study found higher dietary intakes of B6, B12, and folate were associated with improvements in some, but not all, cognitive function measures. In three separate studies, folate intake was not associated with PD or AD; however, in one study, higher folate intake from food sources and/or supplements was associated with a faster rate of cognitive decline after adjusting for multiple risk factors. Among the five studies cross-sectional studies, only two found any significant associations. One found that subjects with low intake of vitamins B1, B2, B6, and folate, but not B12, scored significantly worse on verbal memory than those with relatively high intake levels. Another also found an association between vitamin B2 intake and cognitive testing in women, but not men. No association between dietary intake of B12 and cognitive function or diagnosis of AD was found in all five cross-sectional studies.

#### B Vitamin Status Studies

Vitamin B1. Overall, eight cross-sectional studies evaluated levels of thiamine among AD, cognitively impaired, and PD patients. Thiamine levels were measured in plasma, cerebrospinal fluid (CSF) or autopsied brain. Three studies reported significantly reduced mean thiamine levels in the plasma or brain among AD subjects, and one reported a similar reduction in mean levels of thiamine among PD subjects. However, none of the studies that showed significant results adjusted for potential confounders. The remaining four studies found no differences among the investigated groups.

Vitamin B2. Two cross-sectional studies assessed B2 levels among AD or PD and control groups, which included mixed dementia, vascular dementia, and normal subjects. The study of AD subjects reported no significant difference in riboflavin levels among the groups. The study comparing PD to dementia without stroke found lower B2 levels among those with PD. Neither study adjusted for confounders.

Vitamin B6. Ten studies of various designs examined the potential association of B6 serum levels with the diagnosis of dementia or cognitive impairment, or cognitive function. Only one longitudinal cohort study showed a significant correlation between higher levels of vitamin B6 at baseline in cognitively intact subjects and better performance in the figure copying test after 3 years of follow-up. No other significant correlations were found.

Vitamin B12. Thirty-three studies investigated a potential association between serum B12 levels and cognitive function or diagnosis of several types of dementia and cognitive impairment. Most of the studies focused on AD. Thresholds for B12 deficiency varied across studies. Based on the few longitudinal studies, serum B12 levels are not associated with the risk for developing AD or dementia. However, two of the longitudinal studies reported a correlation between serum vitamin B12 levels at baseline and cognitive function status at the end of follow-up among cognitively intact subjects. Other studies that implemented a cognitive function assessment instrument did not support an association between serum B12 levels and cognitive function. Among cross-sectional studies, there was a trend for B12 serum levels to be lower in patients with AD or other types of dementia, which in certain studies reached statistical significance. However, this trend was not consistent. An inverse correlation between B12 levels and duration of AD was reported by one study. Overall though, there is limited evidence for populations with PD, AD, and vascular dementia. Potential factors such as genetic mutations, or disease severity that may affect B12 levels were analyzed by few studies without revealing any consistent effect.

Folate. Thirty four studies examined folate levels assessed in the red blood cells, plasma, serum, CSF, and blood. Fifteen studies examined the association between folate levels and future cognitive function; ten of the studies were longitudinal and the remainders were case-control or cross-sectional with single time-point analyses. All the studies consistently reported either lower mean folate levels or higher prevalence of folate deficiency among subjects with AD and/or cognitive impairment. Overall, one-third of the studies adjusted for possible confounders. Among studies that assessed the association between folate levels and cognitive function, four longitudinal studies and one case-control study reported a statistically significant association between lowest quantile of folate level and cognitive decline after adjusting for possible confounders. One other case-control study reported significant inverse association of folate with cognitive function. Two studies reported no difference in folate levels between subjects with PD and controls.

Overall. The association between thiamine status and age-related cognitive disorders is unclear. Half the studies found no associations and half found lower levels among AD, cognitively impaired, and PD patients. However, none of these studies could differentiate between cause (low thiamine levels resulting in disease) and effect (changes due to disease, including nutritional intake, resulting in low thiamine levels). The studies also failed to adjust for potential confounders. The cross-sectional studies of B2 found no association with diagnosis of AD, but low levels among people with PD. The large majority of B6 studies found no association between B6 status and the diagnosis of dementia or cognitive impairment, or cognitive function. A large number of studies have evaluated both B12 and folate status. The better, longitudinal studies of B12 failed to find an association with diagnosis or severity of disease. While trends toward lower B12 levels among people with AD were found in cross-sectional studies, these associations were not consistent and proper adjustment for potential confounders was rarely performed. Both the longitudinal and case-control studies of folate status mostly reported an association between low folate levels (defined differently in different studies) and future diagnosis of AD and/or cognitive impairment. No association with PD was found.

Adverse Events. Among the 39 articles reporting on 43 cohorts of subjects taking B vitamin supplements, only 10 reported any information on adverse events. Of these, only two reported that any adverse events occurred. Thiamine was tolerated well in four studies; although initially high doses caused mild gastrointestinal complaints. One of three folate studies reported mild, possibly neurological complaints, that may have been associated with the subjects' PD. No adverse events were noted in one B12 study and in two combination B vitamin studies. No studies reported adverse events for B2 or B6.

### Berries

This report includes evaluations of whole berries, berry extracts, and constituents of berries that were derived directly from the fruits. The following berries were included: bilberry, black raspberry, blackberry, blueberry, boysenberry, cranberry, currants, gooseberry, lingonberry, marionberry, raspberry, and strawberry. However, evidence was found for only bilberries, blueberries, boysenberries, cranberries, currants, gooseberries, and strawberries.

Constituents of Berries. Only a limited number of the numerous constituents in berries have been examined separately from the rest of the fruit. These include tannins, anthocyanins and phenolics, from various berries.

Mechanisms of Action. All studies related to mechanisms of action of berry constituents (or whole berries) have been performed in animal or in vitro models. Among 18 animal or in vitro studies (with 19 experiments) investigating berries and neurocognitive function or processes, four studies examined the effects of specific berry constituents on animal performance in neurocognitive testing or on brain biochemistry. The remaining 14 studies (with 15 experiments) used berry extracts that supplemented normal diet or added to in vitro media.

Effects of the constituents in berries. One study showed that intraperitoneally injected bilberry extract containing anthocyanins significantly increased rat brain uptake of triiodothyronine (T3). A second study measured the concentrations of 18 plant tannins, including blueberry, red currant, and gooseberry, generally inhibit brain protein kinase C to a similar degree; although the biological significance in live animals of this in vitro inhibition is unknown. The third study demonstrated that that the anthocyanins in blueberry extracts were able to cross the BBB and the number of the total anthocyanins measured in the brain is associated with rats' learning performance. The fourth study compared the effects of specific berry constituents on neurocognitive outcomes. Rat performance suggested that there is a range of effectiveness associated with the different berry extracts. However, it does not appear that the anthocyanin component is solely responsible for these improvements. Of note, both the third and fourth studies found no significant effect on rat performance in the Morris Water Maze compared berry to control groups.

Effects of berry extract supplementation. Berry extracts were used to supplement animals' diet or added to in vitro study media in 14 studies with 15 experiments that examined animal performance in neurocognitive testing or brain biochemistry or histology. Of these, two studies used specific animal or in vitro models of AD The remaining 13 studies used adult or aged rat models. Most studies were of good quality. All of these studies were from the same group of investigators.

Only strawberry and blueberry extracts were used to examine the effects of extract supplementation on animal performance in neurocognitive testing or brain biochemistry or histology using a normal-aging rat model. Blueberry and strawberry extract supplementation showed positive or protective effects on almost all biochemical markers and histology findings examined in the rat brain, although only some of the neurocognitive tests and psychomotor functions were significantly improved in these berry-extract-fed rats.

Only two studies used models of AD to examine the effects of various berry extracts. The results suggested that it may be possible to reduce both the deleterious effects of dopamine and the putative toxic effects of amyloid β via various berry extracts as shown in the in vitro study. Results from the animal study that used mice transgenic for amyloid precursor protein and presenilin-1 mutations to model human AD showed that the blueberry extract supplementation seemed to have prevented the deficits in Y-maze performance seen in the transgenic animals fed the control diets, although it did not affect amyloid β deposits.

Human Studies. Only one study evaluated any association between berry (or berry constituent) intake and neurocognitive function. A case-control study of patients with PD, their siblings, and their spouses found that the preference to consume blueberries or strawberries was not statistically significantly associated with presence of PD

Adverse Effects. The single human study of berry consumption was retrospective, therefore no study provided data regarding adverse events from berries in the setting of neurocognitive disorders.

## Limitations

An important limitation to the review of age-related neurocognitive disorders is that only scant research in either humans or animal or in vitro models has been performed related to movement disorders and motor symptom degeneration related to PD and associated diseases.

### Animal and In Vitro Studies

Rodents are the animals most commonly used to model human cognitive dysfunction or age-related cognitive deficits, but many of the behavioral paradigms employed for evaluation of rodent cognitive abilities or functions are fairly different from those generally assessed in humans.^193^ Furthermore, many confounding factors, such as housing conditions, strain, gender, diet, biological rhythms, “stress,” and route of drug administration can affect test data significantly.^194^ There remain substantial controversies surrounding the research findings from animal models of cognitive dysfunction. In particular there is no sound empirical basis for making cross-species generalizations about the neural structures that mediate performance in tasks used to assess memory.^193^ This is most relevant when comparing animal models to human diseases. In addition, the measured outcomes in animal models are indirect measures of the psychological construct in any test of cognitive function. Therefore, the measures of animals' performance in “cognitive tests” are generally not direct or pure measures of cognitive function. For example, age-related deficits in the Morris Water Maze may not be restricted to learning and memory, but may also include deficits in attention, the ability to process spatial information, and the ability to develop efficient spatial search strategies.^187^ It is clear that methodology and procedures of animal models of human cognitive dysfunction are very complex. It is important to avoid simplistic overgeneralizations and inappropriate interpretations of data from animal models of human cognitive dysfunction or age-related cognitive deficits, although this research has generated valuable information about the possible neurobiological basis of the cognitive deficits.

There are a number of limitations specific to our review of the B vitamin and berry literature. The large majority of studies measured performance in otherwise healthy rodents who were made severely deficient in B vitamins. While these studies might elucidate which B vitamins are required for maintenance of brain function, they rarely addressed the question of the actual mechanism of action of the B vitamins. Furthermore, the link between severe vitamin deficiency in normal rodents and the effect of relative vitamin deficiency on human age-related neurocognitive disorders is generally tenuous. Particularly in the case of thiamine deficiency, which is known to result in Wernicke's encephalopathy, the association with AD (or PD) is difficult to ascertain. Studies that linked vitamin deficiencies, vitamin supplementation, or berry supplementation to specific mechanisms of action on nervous tissue were rare and generally provide only a patchy picture of their potential effects.

A major limitation to the data on the potential effects of berries on neurocognitive function is that almost all the studies have been performed in a single laboratory. Replication or similar studies performed by independent groups are necessary before firm conclusions about the putative effects of berries can be made. The constituents in berries that may be responsible for the observed effects on neurocognitive function have yet to be found and the possible mechanisms of action have yet to be fully elucidated.

There remains considerable disagreement about the most meaningful way to assess study quality in human studies, with few analyses attempting to validate specific quality measures. The assessment of study quality in animal and in vitro studies, though, is still in its infancy. No studies have been reported that quantitatively assess the factors that may bias these studies. However, it is clear that improved study design and reporting are necessary.

### Human Studies

Only a single, retrospective, human study of berries and PD has been reported. Thus it is clearly premature to assess the association between consumption of berries or berry constituents and age-related neurocognitive disorders.

Among the human B vitamin studies, the majority were of poor quality. The majority of data come from cross-sectional studies, most of which provided only univariate analyses. Even under the best of circumstances cross-sectional studies cannot differentiate between cause and effect. Thus any associations between B vitamin status and either diagnosis of AD, PD or dementia, or severity of disease may equally be caused by changes in nutrition due to the diseases as by effects of B vitamins on brain function. Many of the associations may also be spurious, since studies rarely attempted to correct for potential confounders such as nutrition status, inflammation status (e.g., homocysteine level), diet, duration of disease, age, sex, genotype, and other factors.

Among the trials of B vitamin supplementation, a large number were either non-randomized comparative trials or non-controlled studies of various designs. These studies are clearly deficient for an adequate assessment of the potential value of B vitamin supplementation. Even among the RCTs the quality of the studies was often poor due to incomplete reporting of methodology and results, lack of blinding, small sample size, short duration, and various other factors.

All the B vitamin studies as a group also suffered from lack of standardization of B vitamin measurement technique, of tissue source (blood, plasma, serum, red blood cell, and cerebrospinal fluid), of normal ranges for B vitamins, of definitions of diagnoses of various dementias, and of tests of cognitive function. In addition, on the order of 50 different tests or subtests were used across the studies. These tests measure different or overlapping domains of cognitive function. Comparisons across studies was thus very difficult. There is also scant evidence regarding the effect of B vitamins on PD.

## Future Research

### Human Studies

Due to either the limited amount of available data or the poor quality of the bulk of the research to date, future well-performed, well-analyzed, large, prospective studies would be necessary to address all the questions posed regarding the effects and associations between either B vitamins or berries and age-related neurocognitive function. However, standardization is clearly needed both in the areas of vitamin research and in neurocognitive disease. Assuming that additional studies are deemed worthwhile by the research community, these future studies should use only well-verified and commonly used measurement techniques for B vitamin status, and where no standardization has yet been agreed upon, this should be a priority. This may require additional research to verify the value of measurement tools for neurocognitive function. Future studies should also use only well-established diagnostic criteria for neurocognitive disorders and should use only measures of cognitive function that have been verified and are commonly used. Studies that use non-standard diagnostic definitions or neurocognitive tests are of limited value to clinicians, policy makers, and other researchers.

Common to most bodies of evidence regarding medical fields, better quality, well-reported, larger and longer duration studies are needed to address the questions of interest. We strongly recommend that all future randomized trials - including those of B vitamins and potentially of berries or berry supplements- use the CONSORT statement as a guide to reporting (www.consort-statement.org).^195,^ ^196^ This will not only improve the readers' understanding of the trials, but should also improve the quality of published studies. The value of non-randomized, and particularly non-controlled, trials is limited.

Further cross-sectional studies evaluating the association between B vitamin status and either diagnosis or severity of disease, with few exceptions are of very limited value. Only those that could include additional data that would give an indication as to cause and effect might be warranted. Additional longitudinal studies are needed to address the questions of the effect of B vitamin status on development of neurocognitive disorders or on the severity of disease. These should either be well-conducted dietary studies using well-established food frequency questionnaire techniques or well-powered, sufficiently analyzed long-term prospective studies. All of these studies of correlations must use appropriate statistical tools, including adjustment for potential confounders and investigation of interactions and sub-groups.

Regarding evaluation of berries and berry constituents, if the animal and in vitro research is deemed to be of sufficient merit to warrant a human study, we would strongly recommend that these studies be more of practical than theoretical value. Trials of extreme diets (i.e., of large daily quantities of berries) or of supplementation with large quantities of berry constituents would not be practical for anyone but research subjects. Even though these studies might help to explain mechanisms of action, they would fail to provide reasonable guidance for those seeking to either prevent or slow neurocognitive decline. Both dietary and supplementation studies should be of doses that a normal person can both easily incorporate into their lifestyle and afford.

### Animal and In Vitro Studies

Animal or in vitro models are especially suitable for investigating the mechanisms of actions of factors that might affect the aging process and the accompanying neurodegenerative changes in human, because the contribution of genetic and environmental factors to the aging process can be strictly controlled in animal or in vitro studies.

Several questions of interest will continue to be difficult to address from human studies given ethical and practical limitations. Topics of particular interest that may be more suitable to animal research include sorting out the independent effects of elevated homocysteine and of low B vitamin levels and/or intake, and clarifying the relative harm of B vitamin deficiency (or benefit of B vitamin supplementation) in different stages of health or neurocognitive disease. Several large observational studies in humans have attempted to address the interaction with homocysteine, however, without the ability to closely control homocysteine and B vitamin levels (or intake) it is unlikely that human studies will definitively answer this question. In addition, for practical reasons, it has been very difficult and thus rare that human studies are able to control sufficient factors to allow full analysis of B vitamin status and neurocognitive status.

Unfortunately many of the tasks or tests available to assess the processes underlying the age-associated deterioration of learning and memory have not been validated. Some insights for future aging research using animal or in vitro models were described in details elsewhere.^193,^ ^194,^ ^197^ Here we summarize their recommendations for future research of age-associated cognitive deficits or normal aging:

1 Identify learning and memory tests that are suitable for longitudinal investigations.
2 Replicate all test conditions.
3 Select behavioral or functional models suitable for testing two or more species. This will enable the comparison of data across species and encourage inter-species comparative studies.
4 Select two or more models, each thought to measure the same cognitive process. This will enable evaluation of the concurrent validities of those models.
5 Measure as many different aspects of performance as possible in as great a resolution as possible.
6 Measure learning/memory as a function of degradation of critical stimuli and/or increasing task difficulty. This will enable estimation of the construct validity of the model.
7 Measure mnemonic and non-mnemonic (such as attention) performance in the same animal in the same test session. This allows a comparative approach to assess the cognitive processes in animals that appear to be activated in humans when performing cognitive tests.
8 Take into account the effects of individual animal variability. Ideally, use a single-subject repeated measures design.

In particular, regarding future studies of berries and berry constituents, future research should elucidate the specific constituents that might be responsible for the observed effects on neurocognitive function. For both berry and B vitamin studies, when possible, experiments should evaluate both the specific mechanisms of action and neurocognitive function, allowing a correlation to be made between the two. However, the need for future animal and in vitro studies to evaluate putative mechanisms of action should be assessed largely based on whether clinical benefits of B vitamins and or berries are found in human trials.