# Results

## B Vitamins

In this section, we summarize the results from human and animal or in vitro studies of the B vitamins - B1 (thiamine), B2 (riboflavin), B6 (pyridoxine and related chemicals), B12 (cobalamin), and folate - in relation to age-related neurodegenerative disorders (primarily Alzheimer's disease [AD] and Parkinson's disease [PD]). The three Key Questions to be answered are as follows:

1 What is the evidence regarding mechanisms of action of the B vitamins B1, B2, B6, B12, and folate (singly and in combination) for preventing, decreasing the rate of progression of, or reversing the neurological changes associated with age-related neurodegenerative conditions such as Parkinson's or Alzheimer's disease?
2 What is the evidence that the B vitamins B1, B2, B6, B12, and folate can prevent, decrease the rate of progression of, or reverse the neurological changes associated with age-related neurodegenerative conditions such as Parkinson's or Alzheimer's disease in humans
3 What adverse events in humans have been reported in the literature for supplementation with the B vitamins B1, B2, B6, B12, and folate?
  a Do the frequency of adverse events vary with source, dose, or other evaluated factors?

Findings are presented in the order of the Key Questions.

The final search of MEDLINE^®^ and CAB Abstracts™ yielded 6,640 citations. This search included human, animal, and in vitro studies. After screening of the titles and abstracts, 183 articles on human studies and 87 articles on animal or in vitro studies. An additional 15 human studies and 1 animal study were found from review articles, study reference lists, and domain experts. From these, 83 human studies and 27 animal or in vitro studies were included in this review. However, though the review covers both neurocognitive function related to AD and related diseases and the movement disorders and motor systems degeneration related to PD and related diseases, only scant evidence was found regarding PD-related conditions.

Qualifying studies are presented in summary tables in the appropriate sections. Details regarding all included studies are available in the evidence tables.^*^

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/berry/berry.pdf.

### Animal and In Vitro Studies: Mechanisms of Action

All studies related to mechanisms of action of B vitamins have been performed in animal or in vitro models. A total of 17 studies were included in this section. Of these, 10 examined the effects of B vitamins on animals' cognitive function, movement disorders and brain neurotransmitters or histopathology (Tables 2–5). Only one in vitro study and one animal study with three publications examined the effects of B vitamins on the expression or function of AD-related genes. Five studies examined the effects of B vitamins on the blood brain barrier (BBB) or cerebrovascular endothelial function (Table 6).

Table 2 Thiamine deficient (intervention) vs. normal thiamine (control) diets

Study, Year | Model Age/Weight | | Duration | Intervention (B1 dose) | N | Control (B1 dose) | N | Neurocognitive Test / Clinical Pathology | Results | P | Histology Measure | Results | P | Quality
Jolicoeur, 1979 (2 papers) | Rats | Male Sprague Dawley, 275–350 g | 44 days | 0 | 6 | Purina Rat Chow (nd) | 6 | Neurological pathology^c^ followed by deaths | + | <.05 | | | | B
| | | | | | | | Catalepsy, rigidity, and landing foot spread | 0
Zimitat, 1990 | Rats | Female Wistar, 9 wk | 35 wk | 0 | 36/11^d^ | 8 or 50 mg/kg of diet^e^ | 36/17^d^ | Ataxia, opisthotonus, moribund | + | <.001 | Hemorrhages, necrosis & vacuolation^g^ | + | nd | B
Terasawa, 1999 | Rats | Wistar, 260–300 g | ~42 days | 30mg/100g of diet | 5 | 60mg/100g of diet | 5 | Time to lever press to stop aversive electrical stimulation | + | nd | | | | C
Ciccia, 2000 | Rats | Male Sprague Dawley, ~2 mo | 8 mo | Vitamin-fortified chow + 3 episodes of TD, each of which lasted ~4.5 wk at wk 10, 18, and 26 of treatment | ~12^f^ | Vitamin-fortified chow + 1 mg/kg BW i.p. 3 times/wk (Monday, Wednesday, Friday) | ~14^f^ | Response time of spontaneous activity | 0 | | | | | B
| | | | | | | | Spontaneous alternation | 0
| | | | | | | | NMTP acquisition trials | 0
| | | | | | | | Delayed NMTP trials | 0
| | | | | | | | Reversal learning MTP | 0
| | | | | | | | Delayed MTP trials | + | <.0001
| | | | | | | | 2nd reversal learning | 0
| | | | | | | | Overall task failure rate | + | nd
| | | | | | | | Clinical signs of neurological or behavioral disturbances | + | nd

Model=Animal, Strain; BW = body weight; i.p. = intraperitoneal; NMTP = nonmatching-to-position; MTP = matching-to-position; wk = week

c Less locomotor activity, lost the righting reflex, displayed impaired weight shift responses

d Number tested for clinical symptoms / Number tested for histopathology

e Control group = 8 mg/kg, 2 thiamine fortified groups = 50 mg/kg. No difference among these groups

f At different stages of behavioral testing, 5 control rats and 2 thiamine deficient rats either died of unknown causes or developed tumors and were killed. Thus, group sizes reported on each behavioral task are different

g Pathologies seen primarily in the medial vestibular nucleus

+ Normal thiamine animals performed better than thiamine-deficient animals

0 No difference between groups

- Normal thiamine animals performed worse than thiamine-deficient animals

Table 3 Vitamin B6 supplementation (intervention) vs. normal B6 (control) diets in healthy animals

Study, Year | Model Age/Weight | | Duration | Intervention (B6 dose) | N | Control (B6 dose) | N | Neurocognitive Test | Groups | Results | P | Quality
Tunnicliff, 1972 | Mice | Male C57BL/6J & DBA/2J inbred strain, 9 wk | 4 wk | 3 μg/day B6-HCl^a^ | 15 | None | | Active escape learning: mean score & variance | All | 0 | | B
| | | | 15 μg/day B6-HCl^a^ | 20 | | | Passive avoidance learning: mean score & variance | All | 0
| | | | 150 μg/day B6-HCl^a^ | 15 | | | Locomotor activity: mean score | All | 0
| | | | | | | | Locomotor activity: variance | 3 μg | Ref
| | | | | | | | | 15 μg | - | <.01
| | | | | | | | | 150 μg | + | <.01
Driskell, 1973 | Rats | Female, 220 g | 3 wk | 15 μg/15 g diet | 6 | None | 6 | Activity and curiosity | 15 μg | - | <.01 | A
| | | | 30 μg/15 g diet | 6 | | | | 30 μg | - | <.01
| | | | 45 μg/15 g diet | 6 | | | | 45 μg | 0
| | | | 60 μg/15 g diet | 6 | | | | 60 μg
| | | | 75 μg/15 g diet | 6 | | | | 75 μg
| | | | 90 μg/15 g diet | 6 | | | | 90 μg
| | | | | | | | T maze | All | 0

B6-HCl = pyridoxine hydrochloride; i.p.= intraperitoneal

a The amount of B6 was estimated based on each animal drank approximately 5 mL of water and ate about 5 g of food each day

+ B6 supplemented animals performed better than normal B6 (or reference) animals, or normal B6 animals performed better than B6-deficient animals

0 No difference between groups

- B6 supplemented animals performed worse than normal B6 (or reference) animals, or normal B6 animals performed worse than B6-deficient animals

Table 4 Vitamin B12 supplements (intervention) vs. normal B12 (control) diets in diseased animals

Study, Year | Model Age/Weight | | Duration | Intervention (B12 dose) | N | Control (B12 dose) | N | Neurocognitive Test | Results | P | Quality
Masuda, 1998 | Rats | Wistar w/ NBM lesions | 10–18 days | 1.0 mg/kg | 10 | Standard rat chow (0.001 mg/kg B12) | 10 | Spontaneous movements | 0 | | A
| | | | | | | | Morris water maze - Acquisition | 0
| | | | | | | | Morris water maze - Retention | 0

i.p. = intraperitoneal; NBM = nucleus basalis magnocellularis; Model = Animal, Strain or cell

+ B12 supplemented animals performed better than normal B12 animals

0 No difference between groups

- B12 supplemented animals performed worse than normal B12 animals

Table 5 Folate deficiency (intervention) vs. normal folate (control) diets

Study, Year | Model Age/Weight | | Duration | Intervention (folate dose) | N | Control (folate dose) | N | Neurocognitive test | Results | P | Biochemical / Histology measure | Results | P | Quality
Deficient - normal animal model
Kim, 2002 | Rats' brains | Male Sprague Dawley, 6 mo | 8 wk | 0 | 8 | 4 mg folate/kg diet | 8 | | | | Degenerative appearance of cerebrocortical microvascular wall | + | nd | A
Duan, 2002 | Mice | C57B1/6, 2 mo, 21–23 g | 3 mo | 0 | 10 | 2 mg folate/kg diet | 10 | Rotarod apparatus (time) | 0 | | Loss of dopaminergic neurons in substantia nigra | 0 | | A
| | | | | | | | Rotarod apparatus (number of falls) | 0
Deficient - Parkinson's disease model
Duan, 2002 | Mice | C57B1/6 2 mo / 21–23 g | 3 mo | 0 mg folate/kg diet + 2 i.p. MPTP (20 mg/kg B.W.) | 10 | 2 mg folate/kg diet + 2 i.p. MPTP (20 mg/kg B.W.) | 10 | Rotarod apparatus (time) | + | <.01 | Loss of dopaminergic neurons in substantia nigra | + | <.01 | A
| | | | | | | | Rotarod apparatus (number of falls) | + | <.01
Deficient - Alzheimer's disease model
Kruman, 2002 | Mice | “Swedish” APP mutant, 7 mo | 3 mo | 0 mg folate/kg + 4.5 gm/kg Hcy diet | nd | Standard mouse diet (folate: nd; Hcy : 0 mg/kg diet) | nd | | | | Aβ deposition | 0 | | B
| | | | | | | | | | | Aβ1–42/Aβ1–40 ratio | 0
| | | | | | | | | | | Loss of neurons in regions CA3 of hippocampus | + | <.0001
| | | | | | | | | | | Loss of neurons in regions CA1 of hippocampus | 0

i.p. = intraperitoneal; Model=Animal, Strain; B.W.=body weight; APP=amyloid precursor protein; Hcy=homocysteine; Aβ=amyloid β-peptide; mo = months; wk = weeks

+ Normal folateanimals performed better than folate deficient animals

0 No difference between groups

- Normal folate animals performed worse than folate deficient animals

Table 6 Effects of B vitamins on blood brain barrier or cerebrovascular endothelial function

Study, Year | Model Age/Weight | | Duration | Intervention (vitamin B dose) | N | Control (Vitamin B dose) | N | BBB or cerebrovascular endothelial function outcomes | | Results | P | Quality
Thiamine deficiency in normal animals
Warnock, 1968 | Rats | Male S D, 50–65 g | nd^a^ | “Thiamine deficient diet” | 15 | “Thiamine adequate diet” | 10 | Pyruvate-2-14C entered the brain directly in adult thiamine deficient animals | | + | nd | B
Robertson, 1971 | Rats | Female Long Evans or Wistar Furth strains, Immature | 28–46 days | Synthetic thiamine-free diet (0) | 46 | Intervention diet w/ thiamine HCl 40 μg/100 g B.W. i.p. | 10 | Integrity of BBB with respect to absence of extra-vascular plasma proteins | Early stage of TD: slight edema; marked spongy reticulation | Ref^c^ | <.001 | B
| | | | | | | | | Late stage of TD: hemorrhages, tissue degradation and neuronal fallout | +
Manz, 1972 | Rats | Female Wistar Furth strains, Immature | 30–45 days | Synthetic thiamine-free diet (0) | 37 | Intervention diet w/ thiamine HCl 40 μg/100 g B.W. i.p. | 12 | Diffuse parenchyma-tous infiltration of the vestibular area | Controls and early stage of TD (edema only) | Ref | <.001 | A
| | | | | | | | | Late stage of TD: hemorrhage and necrosis | +
| | | | | | | | Peroxidase was deposited in the contraluminal side basement membrane zone of intercellular gaps, but interendothelial junctional complexes were morphologically intact, in rat brains with late stage of TD | | | nd
Folate Supplementation in deceased animals
Lee, 2004 | Rats^b^ | Male S-D, 8 wk | 2 wk | 8 mg/kg diet + 0.3% Hcy | 6 | 0.3% Hcy | 6 | Cerebral expression level of GLUT-1 | | + | .04 | A
| | | | | | | | Cerebral expression level of VCAM-1 | | - | .04
| | | | | | | | Endothelial nitric oxide synthase | | + | .04
Lee, 2005 | Rats^b^ | Male S-D, 8 wk | 8 wk | 8 mg/kg diet + 0.3% Hcy | 4 | 0.3% Hcy | 4 | Cerebral expression level of GLUT-1 | | + | <.05 | A
| | | | | | | | Damaged cerebral capillary wall structure | | + | nd
| | | | | | | | % Damaged vessels in the hippocampus | | + | <.05

BBB = blood brain barrier; S-D=Sprague-Dawley; Hcy=homocysteine; GLUT-1=glucose transporter protein; VCAM 1= vascular cell adhesion molecule; i.p.= intraperitoneal; B.W.=body weight; TD=thiamine deficiency

a At first signs of polyneuritis

b Rats were fed a diet with 0.3% Hcy for 2 weeks before allocated to the intervention or control diets described in the table. All rats had induced hyperhomocysteinemia before the allocation.

c Extravascular fluorescence was not seen in control animals (n=10)

+ B vitamin deficient animals have abnormal function while normal B vitamin animals have normal function, or B vitamin supplemented animals have better function than normal B vitamin animals

0 No difference between groups

- B vitamin supplemented animals have worse function than normal B vitamin animals

#### Effects of B Vitamins on Cognitive Function, Movement Disorders, and Brain Neurotransmitters or Histopathology

Study Descriptions. The effects of B vitamins on cognitive function, movement disorders and brain neurotransmitters or histopathology in animal and in vitro models were described in 10 studies in 11 publications.^26,^ ^27,^ ^34^–^42^ Four studies in five publications used thiamine deficient models in rats. Three studies were of moderate quality, and one was of poor quality (Table 2). Two examined the effects of B6 treatments on animals' performances in neurocognitive tests. One was of high quality and the other one was of moderate quality (Table 3). One high quality study used models of vitamin B12 supplementation in rats.(Table 4). Three studies used folate deficient models alone or in combination with PD or AD models in mice or rats. Three studies were of high quality and one of moderate quality (Table 5). We found no study that examined the effects of riboflavin (vitamin B2) or mixed vitamin B treatments on outcomes of interest.

##### Overall Effects

Thiamine (B1). The overall findings of the effects of thiamine deficiency are summarized in Figure 1. Of the four studies (in five publications) using thiamine-deficient models, two examined the rats' clinical status and/or histopathology after 44 days or 35 weeks of thiamine-depleted diets, and three examined rats' performance in neurocognitive tests (Table 2).^34^–^36,^ ^38,^ ^39^ The two studies that examined the rats' clinical status and/or histopathology found that a diet without thiamine significantly damaged the rats' brains and/or caused serious neurological pathology, including death. In the other two studies that examined the effects of thiamine deficiency on rats' performance in neurocognitive tests, the deficient regimens varied widely. Specifically, Terasawa 1999 fed the rats a low-thiamine diet (30 mg per 100 g diet) for approximately 42 days, and Ciccia 2000 fed the rats a vitamin-fortified chow in combination with a thrice-weekly thiamine injection (1 mg per kg body weight) for three episodes of thiamine deficiency. Each episode lasted about 4.5 weeks. Terasawa 1999 found rats fed thiamine-deficient diets had significantly impaired performances in the neurocognitive tests when compared to the control rats. Ciccia 2000 found that rats with three separate episodes of thiamine deficiency had significantly impaired performance in two of eight neurocognitive tests.

Figure 1. Summary findings of the effects of thiamine deficiency on rats' cognitive function, movement disorders and brain histopathology

Pyridoxine (B6). Two studies used a vitamin B6-supplementation model in mice or rats and both studies examined different doses of B6 supplementation on performances in neurocognitive tests (Table 3).^41,^ ^42^ No significant effects of B6 supplementation were found for rat learning or cognitive function. Dietary B6 supplementations showed some positive effect on motor function or behavior, although the effects were not consistent across the two studies. The studies did not find a linear dose-response relationship for the effects; however, the results suggested worse motor function was associated with a lower dose of dietary B6 supplementation.

Cyanocobalamin (B12). One study examined the effects of low-dose vitamin B12 supplementation on spontaneous movements and performance in the Morris Water Maze in rats with nucleus basalis magnocellularis (NBM) lesions (an animal model that mimics some of the cholinergic hypofunction and memory loss associated with AD; Table 4).^37^ The study found that low dose (1 mg per kg diet) vitamin B12 supplementation alone had no significant effect on spontaneous movements and did not improve memory in rats with NBM lesions.

Folate. Three studies examined the effects of folate deficiency on animal performance in neurocognitive tests and on brain neurotransmitters or histopathology; two used a normal animal model, one used a PD model and one used an AD model (Table 5).^26,^ ^27,^ ^40^ Kim 2002 conducted a electron microscopic experiment comparing the cerebrocortical microvascular wall in brain cross sections with rats fed a diet without folate to that of rats fed a diet with folate (4 mg per kg diet). After 8 weeks of dietary treatments, a degenerative appearance of the cerebrocortical microvascular wall occurred in rats fed folate-deficient diet, while rats fed a diet with folate had a normal cerebral capillary wall. Duan 2002 tested the effects of folate deficiency using a rat model of PD. After 3 months of dietary treatments, both experiment and control animals received two intraperitoneal injections of 20 mg 1-methyl-4-phenyl-1,2,3,6-tetrahydropyridine (MPTP) per kilogram body weight. The MPTP toxin induced PD-like pathology and behavioral symptoms. In contrast to mice on the control diet that were resistant to the sub-toxic dose of MPTP, mice maintained on the folate-deficient diet exhibited profound motor dysfunction as indicated by a decrease in the period of time in which they were able to maintain themselves on the rotarod and by an increased number of falls. However, folate deficiency alone did not impair rats' performance on rotarod tests. Kruman 2002 examined the effects of folate deficiency on brain histology findings in amyloid precursor protein (APP) mutant mice. These mice developed age-dependent deposition of amyloid β-peptide in their brains. There was no significant difference in the levels of amyloid β deposition between APP mutant mice on the folate-deficient diet and those on the control diet. However, the analyses in the CA3 region of the hippocampus revealed a highly significant 20 percent loss of neurons in APP mutant mice on the folate-deficient diet compared with those on the control diets. These results suggested that folate deficiency renders hippocampal CA3 neurons in APP mutant mice vulnerable to death by a mechanism that does not involve increased amyloid β production or deposition.

Summary. Of the four studies that used thiamine-deficient models, two examined the rats' clinical status and/or histopathology after thiamine-depletion diets and all found that thiamine-depletion diets significantly damaged brain and/or cause serious neurological pathology, including death. The remaining two studies that examined rat performance in neurocognitive tests found that thiamine deficiency had significantly impaired performance in some neurocognitive tests.

Two studies used a B6-supplementation model in mice or rats to examine the effects of B6 treatments on performance in neurocognitive tests. Both studies that used the B6-supplementation model examined various doses of B6 supplementation on animal performance in neurocognitive tests. No significant effects of B6 supplementation were found on rats learning or cognitive function. Dietary B6 supplementations showed some positive effect on animal motor function or behavior, although the effects were not consistent across the two studies and did not show a linear dose-response relationship.

One study showed that low dose (1 mg per kg diet) vitamin B12 supplementation alone had no significant effect on spontaneous movements and did not improve memory in rats with NBM lesions.

Of the three studies that examined the effects of folate deficiency on animal performance in neurocognitive tests and brain neurotransmitters or histopathology, two used a normal animal model, one each used a PD model and an AD model. Results from the normal animal model showed a degenerative appearance of the cerebrocortical microvascular wall was shown in rats fed a folate-deficient diet for 8 weeks, but 3-month folate-deficient diet did not impair rats' performance on rotarod tests. The one study that tested the effects of folate deficiency using a rat model of PD found that mice which had been maintained on the folate-deficient diet exhibited profound motor dysfunction induced by MPTP, in contrast to mice on the control diet that were resistant to the sub-toxic dose of MPTP. The results from the one study that used an AD model to examine the effects of folate deficiency on brain histology findings in APP mutant mice suggested that folate deficiency renders hippocampal CA3 neurons in APP mutant mice vulnerable to death by a mechanism that dose not involve increased amyloid β production or deposition.

We found no study that examined the effects of riboflavin (B2) or mixed B vitamin treatments on outcomes of interest.

Overall, research has shown that there were negative effects of thiamine and folate deficiency or deprivation on animal's clinical status and/or histopathology, although not all deficient animals had worse performance in neurocognitive tests. Studies have found some positive effects of the supplementations of B6, B12, and folate on animal's performance in neurocognitive tests, but studies did not show a dose-response relationship. Only folate deficiency was examined in animal models of AD and PD; the results showed a synergistic effect with both PD and AD pathology.

Summary Findings From Studies Using Immature Animals. Eight studies in nine publications were not included in detail in this review because immature rodents were used.^43^–^51^ In these studies, young rodents were treated for a short period time and tested before their growth ceased. Though these studies are not applicable to questions concerning “age-related neurodegenerative” changes, it is of interest how these studies compare to those with more appropriate models. Of the eight studies, three used thiamine-deficient models, two used B6-deficient models, two used a B12-supplementation model, and one used folate-deficient model. The results from these studies were similar to those summarized in this report. Detailed data can be found in the evidence tables.^*^

#### Effects of B Vitamins on the Expression or Function of Alzheimer's Disease-Related Genes

Study Descriptions. Only one animal study with 3 publications^52^–^54^ and one in vitro study^55^ examined the effects of B vitamins on the expression or function of AD-related genes. Both are of high quality.

Overall Effects. Shea et al. published a series of papers to test a hypothesis that deficiencies in apolipoprotein E gene (ApoE) function are associated with increased oxidative stress in the central nervous system (CNS). ApoE can promote neuronal survival and outgrowth and may play important roles in adaptive responses to aging and brain injury.^11^ The experiments were carried out by comparing the responses of transgenic mice lacking ApoE with those of normal mice of the identical genetic background to dietary oxidative stress induced by folate deprivation and by inclusion of excess iron in their diet. The mice used in this series of experiments were overlapped. (The source of this information was a personal communication with the authors.) Both transgenic mice and normal mice were fed either an experimental diet (without folate) or a control diet (with 4 mg folic acid per kilogram of diet) for 1 month; then harvested total CNS tissue was analyzed for thiobarbituric acid-reactive substances (TBARS, an end-point index of oxidative damage), and total antioxidant capacity in CNS. ApoE-deficient mice were found to have significantly increased TBARS when challenged with iron (which induces oxidation) in the absence of folate, in contrast to ApoE-deficient mice challenged with iron in the presence of folate and to normal mice, regardless of folate or iron status. Furthermore, antioxidant capacity was lower in ApoE-deficient mice receiving iron in the absence of folate compared to same mice receiving folate or compared to normal mice, regardless of folate status. These results suggest that the genetic deficiency of a complete absence of ApoE could be alleviated with 4 mg/kg body weight folic acid repletion for 1 month. This is proposed as a partial explanation as to why certain ApoE alleles are associated with increased prevalence and earlier onset of AD.

Fuso 2005 conducted an in vitro study using neuroblastoma cell lines and examined the effects of folate and vitamin B12 deficiency on AD gene and protein expression. Specifically, they examined APP, presenilin-1 (PS1) and presenilin-2 (PS2), the genes linked to familial AD.^11^ For the purpose of this review, we chose the most appropriate comparisons for our questions of interest, which were the results from cells grown in the vitamin deprived media versus cells grown in the differentiation media, because the only difference in the contents of these two media are the amount of folate and B12. The results showed that folate and vitamin B12 deprivation did not change APP or PS2 gene and protein expressions, but increased PS1 gene and protein expression.

Summary. A series of animal experiments showed that ApoE-gene knockout mice are less capable of buffering oxidative challenge in CNS than the normal mice, and the genetic deficiency of a complete absence of ApoE could be alleviated with folate repletion. The results from the other in vitro study demonstrated that an increase in PS1 gene could be induced by folate and vitamin B12 deprivation. The other genes involved in APP processing, and APP itself seemed to be independent of folate and vitamin B12 deprivation.

#### Effects of B Vitamins on Blood Brain Barrier or Cerebrovascular Endothelial Function

Study Descriptions. Five studies on the effects of B vitamins on BBB or cerebrovascular enthothelial function are included in this section (Table 6).^56^–^60^ Of these, two moderate quality studies and one high quality study examined BBB transport and permeability in normal and thiamine-deficient rats. Two high quality studies examined the effects of dietary folate supplementation on cerebral endothelial function and cerebral vascular damage induced by hyperhomocysteinemia in vivo.

##### Overall Effects

Thiamine (B1) deficiency. Warnock 1968 examined pyruvate metabolism and the differences in pyruvate transport across BBB, comparing normal rats to thiamine-deficient rats.58 The results showed that labeled pyruvate entered the brain directly in adult thiamine-deficient animals, while it did not directly enter the brain of normal adult animals. This indicated that selective transport across BBB was not functioning in a normal fashion in thiamine-deficient rats. Robertson 1971 evaluated the presence or absence of extravascular fluorescence bound to intraperitoneally administered bovine albumin in relation to the severity of BBB lesions.^60^ They found that extravascular fluorescence was present in one of 24 rat brains from animals with early stage of thiamine deficiency (as indicated histologically by slight edema, or more marked spongy reticulation, frequently accompanied by vascular congestion). Extravascular fluorescence was present in 12 of 22 rat brains from animals with late stage of thiamine deficiency (as indicated histologically by hemorrhages, tissue degradation and neuronal fallout). There was no extravascular fluorescence seen in rat brains from control animals. These results suggested that BBB is intact with respect to albumin in the early lesions of thiamine deficiency. Thus intracellular edema associated with early deficiency results from a defect in cell membrane transport rather than a vascular leak of the inflammatory type across BBB. A follow-up study by Manz 1972 employed a similar protocol to further define the nature and sequence of permeability changes of the BBB, using horseradish peroxidase (a low molecular weight protein marker).^59^ It was found that control rats and rats with early stages of thiamine deficiency had “qualitatively and quantitatively” the same pattern of peroxidase granules in phagocytes. None of the rats with early stage of thiamine deficiency had parenchymatous infiltration, while 21 of 30 rats with late stage thiamine deficiency did. Furthermore, control rats and rats with early stage of thiamine deficiency were devoid of peroxidase in the vascular basement membrane and the neural parenchyma. Although the interendothelial junctional complexes were morphologically intact in rats with late stage of thiamine deficiency, reaction product was deposited in the contraluminal side basement membrane zone of intercellular gaps. These results suggested that BBB damage seen in later stages corresponds to damage seen from cold-injury edema and other models of cerebral edema. The leakage of BBB appears to be predominantly through the mechanism of pinocytosis (introduction of fluids into a cell by invagination of the cell membrane, followed by formation of vesicles within the cells), not disruption of interendothelial junctions.

Folate supplementation. Lee et al. conducted a series of studies to examine the effects of dietary folate supplementation on cerebral endothelial function and cerebral vascular damage induced by hyperhomocysteinemia in vivo. Before allocation to dietary intervention, all rats were fed a diet with added homocysteine (3.0 g per kg diet) for 2 weeks to induce hyperhomocysteinemia along with the hyperhomocysteinemia-induced cerebrovascular endothelial dysfunction. The first study found that 2 weeks of dietary folate supplementation significantly ameliorated the hyperhomocysteinemia-induced cerebrovascular endothelial dysfunction, characterized by reduced endothelial nitric oxide synthase (eNOS) activity and glucose transporter protein (GLUT-1) activity. Specifically, the level of brain eNOS protein expression increased by 44 percent (P=0.04) and the GLUT-1 level increased by 27 percent (P=0.04), in the comparison of rats fed an additional 8 mg per kg diet of folate to those on homocysteine diet. However, an unexpected result was observed for the cerebral content of the vascular cell adhesion molecule (VCAM-1). Rats fed an additional 8 mg per kg diet of folate had a 43 percent (P=0.04) decrease in VCAM-1 level. A subsequent study evaluated the effects of 8 weeks of dietary folate supplementation on cerebral vascular damage induced by hyperhomocysteinemia in vivo, in particular, investigating the structural features of the cerebral vasculature by electron microscopy. Consistent with the results from the first study, folate supplementation significantly increased the cerebral GLUT-1 protein, which had been decreased by a homocysteine diet. In the folate supplemented group, damaged vessels, annihilation of cell organelles, degeneration of mitochondrial bilayer, and perivascular detachment were also observed, although the damage of the cerebral vasculature was described as “more serious” in rats fed homocysteine-supplemented diet. In addition, dietary supplementation with folate for 8 weeks significantly reduced the percentage of damaged vessels.

Summary. Three studies examined BBB transport and permeability showed an abnormal selective transport of pyruvate across BBB in adult thiamine-deficient animals and intracellular edema associated with early deficiency results from a defect in cell membrane transport rather than a vascular leak of the inflammatory type across BBB. The leakage of BBB appears to be predominantly through the mechanism of pinocytosis, not disruption of interendothelial junctions. Two studies examined the effects of dietary folate supplementation on cerebral endothelial function and cerebral vascular damage induced by hyperhomocysteinemia in vivo. The results suggest that folate supplementation may ameliorate the hyperhomocysteinemia-induced cerebrovascular endothelial dysfunction and reduce cerebrovascular damage induced by hyperhomocysteinemia.

### Human Studies

The human studies addressing the evidence of the effect of B vitamins on age-related neurodegenerative conditions fall into three types, which will be discussed in the following order: intervention trials, studies of associations between B vitamin intake and neurocognitive function, and studies of association B vitamin tissue levels and neurocognitive function.

Among the 85 human studies reviewed, 30 were intervention trials, eight were B vitamin intake association studies, and 52 were B vitamin level association studies. Five studies reported data on both interventions and associations (at baseline). The large majority of studies were deemed to be of poor quality. Overall, three studies were of good quality, 25 of fair quality, and 57 of poor quality. The most common reasons for grading study quality poor were lack of randomization or control in intervention studies, lack of adjustment for potential confounders in association studies, and poor or inadequate reporting of study design and results. Overall, 23 studies had broad applicability, 40 had moderate applicability, and 23 had narrow applicability, often due to small sample size or focus on a specific population of diseased individuals. (One article contained two studies with different applicability ratings.)

Tables 7 and 8 provide an overall summary of the number of studies, number of subjects, quality, applicability, and summarized results of the evidence for B vitamin intervention (Table 7) and B vitamin intake and levels associations (Table 8) with neurocognitive conditions.

Table 7 Summary of intervention studies evaluating the effect of B vitamins on neurocognitive outcomes

| [underlined: INTERVENTION STUDIES]
| [underlined: Change Severity] | | | | | [underlined: Prevent/Delay Disease]
Vitamin | Studies | N | Quality | Applicability | Results | Studies | N | Quality | Applicability | Results
B1 | 5 | 79 | A 0 | III 0 | ↔ | 1 | 32 | A 0 | III 0 | ↑
| | | B 0 | II 2 | | | | B 0 | II 1
| | | C 5 | I 3 | | | | C 1 | I 0
B2 | 0 | | | | | 0
B6 | 2 | 151 | A 0 | III 0 | ↔ | 0
| | | B 1 | II 1
| | | C 1 | I 1
B12 | 12 | 492 | A 1 | III 0 | ↔ | 1 | 14 | A 0 | III 0 | ↑
| | | B 2 | II 5 | | | | B 0 | II 0
| | | C 10 | I 8 | | | | C 1 | I 1
Folate | 5 | 168 | A 0 | III 0 | ↔ | 0
| | | B 2 | II 3
| | | C 3 | I 2
Mix | 6 | 462 | A 0 | III 1 | ↔ | 0
| | | B 2 | II 4
| | | C 4 | I 1

Quality: A = good quality; B = fair quality; C = poor quality.

Applicability: III = widely applicable; II = moderately applicable; I = narrowly applicable.

Results: ↑ = treatment with, higher intake of, or higher level of associated with beneficial outcome (lessened severity, lower incidence)

↔ = no association

↓ = associated with worsened outcome (increased severity, higher incidence).

Table 8 Summary of association studies evaluating the association of B vitamin intake or levels on neurocognitive outcomes

| [underlined: INTAKE STUDIES] | | | | | | | | | | [underlined: LEVELS STUDIES]
| [underlined: Associated w/Severity] | | | | | [underlined: Associatedw/Prevalence or Incidence] | | | | | [underlined: Associatedw/Diagnosis] | | | | | [underlined: Associated w/Severity]
Vitamin | Studies | N | Quality | Applicability | Results | Studies | N | Quality | Applicability | Results | Studies | N | Quality | Applicability | Results | Studies | N | Quality | Applicability | Results
B1 | 3 | 727 | A 0 | III 0 | ↔ | 1 | 62 | A 0 | III 0 | ↔ | 7 | 394 | A 0 | III 2 | ↔ | 1 | 201 | A 0 | III 1 | ↔
| | | B 2 | II 3 | | | | B 0 | II 1 | | | | B 1 | II 2 | | | | B 1 | II 0
| | | C 1 | I 0 | | | | C 1 | I 0 | | | | C 3 | I 3 | | | | C 0 | I 0
B2 | 3 | 727 | A 0 | III 0 | ↔ | 1 | 62 | A 0 | III 0 | ↔ | 2 | 154 | A 0 | III 0 | ↔ | | 0
| | | B 2 | II 3 | | | | B 0 | II 1 | | | | B 0 | II 2
| | | C 1 | I 0 | | | | C 1 | I 0 | | | | C 2 | I 0
B6 | 4 | 539 | A 0 | III 0 | ↔ | 2 | 136,185 | A 1 | III 2 | ↔ | 8 | 1,587 | A 0 | III 2 | ↔ | 2 | 141 | A 0 | III 0 | ↔
| | | B 3 | II 3 | | | | B 0 | II 0 | | | | B 2 | II 3 | | | | B 2 | II 2
| | | C 1 | I 1 | | | | C 1 | I 0 | | | | C 6 | I 3 | | | | C 0 | I 0
B12 | 3 | 530 | A 0 | III 0 | ↔ | 2 | 136,120 | A 1 | III 1 | ↔ | 26 | 8,093 | A 1 | III 12 | ↔ | 7 | 2,618 | A 0 | III 2 | ↔
| | | B 3 | II 2 | | | | B 0 | II 1 | | | | B 9 | II 10 | | | | B 5 | II 4
| | | C 1 | I 1 | | | | C 1 | I 0 | | | | C 16 | I 4 | | | | C 2 | I 1
Folate | 3 | 530 | A 0 | III 0 | ↔ | 3 | 136,248 | A 1 | III 2 | ↔ | 28 | 8445 | A 1 | III 10 | ↑ | 6 | 1,663 | A 0 | III 3 | ↔
| | | B 3 | II 2 | | | | B 0 | II 1 | | | | B 11 | II 17 | | | | B 4 | II 2
| | | C 1 | I 1 | | | | C 2 | I 0 | | | | C 16 | I 1 | | | | C 2 | I 1

Quality: A = good quality; B = fair quality; C = poor quality.

Applicability: III = widely applicable; II = moderately applicable; I = narrowly applicable.

Results: ↑ = treatment with, higher intake of, or higher level of associated with beneficial outcome (lessened severity, lower incidence)

↔ = no association

↓ = associated with worsened outcome (increased severity, higher incidence).

Table 9 Effect of thiamine (vitamin B1) intervention on cognitive function tests

[table image]

Table 10 Effect of vitamin B6 intervention on cognitive function tests

[table image]

#### Effect of B Vitamin Supplementation on Neurocognitive Function

##### Thiamine (Vitamin B1) Intervention Studies

Study Descriptions. Three randomized controlled trials (RCTs),^61^–^63^ one non-randomized comparative trial (N-RCT), ^62^ and one uncontrolled cohort study ^64^ reported data on thiamine supplementation among patients with probable or possible AD in four articles. All studies included subjects whose mean ages were greater than 70 years, and who met standard criteria for diagnosis of probable or possible dementia. Their average mini-mental status examination (MMSE) scores ranged from 14 to 18, indicating moderate to mild dementia. All RCTs tested three divided doses of 3 g per day thiamine, the N-RCT tested a maximum of 8 g per day thiamine and the single arm intervention trial tested a dose of 750 mg of a thiamine derivative. Thus, most studies used high-dose interventions compared to the US Recommended Daily Allowance (RDA) of 1.1 to 1.2 mg daily. The primary outcome for all studies was cognitive function (measured with MMSE or Alzheimer's Disease Assessment Scale [ADAS]). In addition, two of the studies evaluated outcomes on behavior and/or emotion.61,64 All studies had small sample sizes (fewer than 25 subjects). All studies were assessed to poor quality (C). Two studies have moderate applicability and three narrow applicability.

Overall Effect. Three of the five studies reported statistically significant effects in cognitive function after intervention with thiamine for short durations (1 to 3 months).^61,^ ^62,^ ^64^ Meador 1993 reported statistically significant improvement of cognitive score (ADAS) in the initial months with reduced deterioration at 11 to 13 months, suggesting some beneficial effect of high dose of thiamine in decreasing the rate of progression of AD. This study also reported clinically significant effect of thiamine supplementation in the majority of subjects at dosages above 4 g per day.

Among these, Blass 1988 was a randomized crossover trial. The study did not document a wash out phase and compared thiamine to the intervention of niacinamide 750 mg as an active placebo. The follow-up study to Blass 1988, by Nolan 1991, was an RCT with parallel design that compared thiamine treatment to lactose placebo. It found no significant effects on cognitive function after treating to the same dose of thiamine for one year.

Meador 1993 reported two different experiments, and tested higher doses of thiamine (greater than 3 g per day). The first was a crossover RCT that compared thiamine to placebo without a washout phase between treatments. The second was a non-randomized comparative trial, which gave AD subjects sequentially higher doses of thiamine followed by placebo, and reported statistically significant improvements in the cognitive score (ADAS) at 3 dosages of 4 g per day or more thiamine. Of note this thiamine supplementation study reported improvement in the scores of Clinical Global Impression of Change (CGIC), which is a physician rated assessment of overall change from the baseline. However the study reported results among fewer than 10 subjects for dosages of 7 g or more between 8 to 13 months.

Mimori 1996 was an uncontrolled cohort study that used fursultiamine, a thiamine derivative that is easily converted into an active form of thiamine in the body. They evaluated nine people with AD and normal mean levels of blood thiamine. The study reported a statistically significant improvement in cognitive function (MMSE) and the emotional component of the Gottfries-Brane-Steen (GBS) score after the intervention with fursultiamine. Blood thiamine levels increased markedly after fursultiamine intervention.

Interactions and Covariates. In its second experiment, Meador 1993 tested a maximum dose of thiamine for 13 months. The first phase of the study the thiamine dose was incrementally increased each month to a maximum of 6 g per day. In the second phase a “best dose” (defined as achievement of best ADAS scores) was used, and in the third phase a maximum dose of 8 g per day was achieved. However, after month 5, the results for the doses greater than 6 g of thiamine were reported only in a small subset of two to six subjects. High dose thiamine significantly reduced ADAS scores compared to baseline, but MMSE showed no significant change. No other interactions were reported in the studies. Only the uncontrolled cohort study reported blood levels of thiamine before intervention, and included subjects with normal blood levels. All the studies of thiamine intervention used tests of the same domain and measured global cognitive function as the outcome.

Summary. Five poor quality studies assessed in four articles reported data on the effect of thiamine intervention among people with probable or possible AD. Overall, two RCTs, and one cohort study reported improvement in cognitive function during short-term treatment of thiamine. However, without a comparable control group, it is difficult to assess the validity of the uncontrolled cohort study given the variable course of dementia over time. Two long-term studies failed to show any discernable differences in cognitive function as measured by MMSE. However the N-RCT that supplemented AD subjects with progressively higher doses of thiamine followed by placebo reported statistically significant improvement of cognitive score (ADAS) in the initial months with reduced deterioration at 11 to 13 months, suggesting some beneficial effect of high dose of thiamine intervention. This study also reported long-term clinical benefit from thiamine intervention.

##### Riboflavin (Vitamin B2) Intervention Studies

No prospective trial has evaluated the effect of vitamin B2 treatment on neurocognitive function.

##### Vitamin B6 Intervention Studies

Study Descriptions. Two RCTs assessed the effect of B6 intervention on cognitive function in humans.^65,^ ^66^ They included 75 and 38 cognitively intact subjects in the intervention arm respectively. One RCT used 75 mg of B6 per day for 5 weeks while the other trial administered 20 mg of B6 per day for 12 weeks. Both doses are considerably higher than the US RDA dose of 1.3 to 1.7 mg daily. One study used digit symbol coding, vocabulary test, and digit span-backwards from WAIS III as well as the Stroop test for executive function and initial letter for verbal fluency. The second RCT applied the Associate Recognition Task and the Long Term Memory Storage to assess cognitive function. The trials were of moderate (B) and low (C) quality and had narrow and moderate applicability, respectively.

Overall Effect. Deijen 1992 reported a significant decrease in Long Term Memory Storage for the intervention group, which corresponds to memory improvement (P<0.03). However, no significant effect was recorded in the Associate Recognition Task for the intervention group in the same study. However, no formal comparison between intervention and placebo group was provided in the article and no information is given for the significance of the changes in the placebo group.

Interactions and Covariates. There is no adequate evidence to support any dose effect of B6 on the outcomes. There was no evidence across studies of differences in effect on tests of different cognitive domains. No other interactions were reported in the studies.

Summary. Two RCTs of moderate and low quality, with narrow and moderate applicability for cognitively intact populations investigated the effect of B6 intervention on cognitive function in humans. With treatment, a significant improvement was found with one cognitive function test. It is uncertain whether this change is of any clinical benefit. It is also unclear whether the changes with treatment were significantly different than changes in the control arm in the same study. No other significant effect was reported in the studies. Because of the very limited evidence no conclusions can be drawn for the effect of B6 on preventing cognitive function decline.

##### Cobalamin (Vitamin B12) Intervention Studies

Study Descriptions. Five RCTs, one N-RCT, and seven uncontrolled cohort studies assessed the effect of B12 intervention on cognitive function in humans.^65,^ ^67^–^78^ Among the RCTs (Table 11) sample size ranged from 18 to 70 in the intervention arms. Two RCTs recruited cognitively intact participants with normal B12 while another two recruited cognitively intact subjects with low B12 levels. Low B12 levels was defined as 136 to 203 pg/mL in one RCT and less than 163 pg/mL in the other. The fifth RCT included subjects with cognitive impairment. The five RCTs used different doses and routes of B12 interventions ranging from 0.01 mg B12 per day orally to 1 mg 3 times per week B12, intramuscularly. Two trials used oral B12, the remainder intramuscular. B12 doses were higher than the US RDA of 2.4 μg per day. Almost all trials implemented more than one cognitive function test. MMSE was used by three trials, several parts of the Wechsler Adult Intelligence Scale (WAIS) by two trials while a number of miscellaneous tests were also reported (Table 12)., including the Cognitive Subscale of Cambridge Examination for Mental Disorders of the Elderly (CAMCOG), 12 word learning test - immediate and delayed - Stroop, initial letter from verbal fluency, memory quotient, lower and upper limit of retention span, visual and verbal memory, verbal and performance Intelligence Quotient (IQ). RCTs were of moderate to low quality (1A, 2B, 2C) and had narrow to moderate applicability.

Table 11 Effect of vitamin B12 intervention on cognitive function tests in randomized controlled trials

[table image]

Table 12 Effect of vitamin B12 intervention on cognitive function tests in non-randomized trials

[table image]

Among the N-RCT and the cohort studies (Table 12), sample size ranged between 14 and 56. Three studies recruited demented participants, regardless of specific diagnosis. Two selected only participants with low serum B12 levels defined as less than 200 pg/mL in one trial and less that 300 pg/mL in the other trial. There were three additional trials that included subjects with low B12 levels (less than approximately 200 pg/mL); one recruited cognitively impaired individuals with B12 less than 203 pg/mL and the other included cognitively intact persons with B12 values equal or less than 203 pg/mL while the third one evaluated patients with AD or other dementias and B12 values less than 190 pg/mL. Two other studies included subjects with AD, regardless of B12 status. As with the RCTs, cobalamin doses were considerably higher than the RDA. Almost all trials implemented more than one cognitive function test (Table 12). MMSE was used by five trials, Mattis' Dementia Rating Scale (DRS) by two studies, WAIS by one trial, GBS by two trials while a number of miscellaneous tests were also reported, including CAMCOG, Interview for Deterioration in Daily living activities in Dementia (IDDD) -Initiative, IDDD-Performance, Revised Memory and Behavioral Problems (RMBPC) -Memory, RMBPC-Disruptive behavior, delayed verbal word learning test, verbal fluency, similarities, trail making test, Rivermead behavioral face recognition test, Hasegawa's Dementia Rating Scale (HDS), and Consortium to Establish a Registry for Alzheimer's Disease (CERAD). The N-RCT was of low quality and had moderate applicability. Cohort studies were (by definition) of low quality (C) and had narrow to moderate applicability.

Table 13 Effect of folic acid or folate intervention on cognitive function tests

[table image]

Table 14 Effect of combination B vitamin interventions on cognitive function

[table image]

Overall Effect. Only one RCT (Hvas 2004) found a significant difference in effect on 12 word learning test at 15 minutes between the B12 and the control groups among cognitively impaired subjects. With other tests, some significant changes were found either with or without B12 supplementation, but these changes were not significantly different than each other. Kwok 1998, which included cognitively intact participants with low B12 (<163 pg/mL) revealed a significant improvement for B12 group in performance IQ; however, this was not significantly higher than the change in the control group. No other significant effects were reported in the RCTs.

Among the seven uncontrolled cohort studies, Teunisse 1996 reported that MMSE score was significantly worse after treatment among demented individuals with low B12 levels (<200 pg/mL). Ikeda 1992 found a significant improvement in Mattis' DMR scale at 2 months among people with AD, which however, was not maintained 4 months after the end of treatment. In the same study, GBS and HDS were also significantly improved at the end of treatment, but their improvement was also not maintained 4 months later. Van Asselt 2001, in the N-RCT, found that after treatment, performance on the delayed recall of verbal word learning test, similarities and verbal fluency test was significantly improved among cognitively intact subjects with low B12 (<203 pg/mL). In contrast, Teunisse 1996 noted significant deterioration in several tests including IDDD-Initiative, IDDD-Performance, and RMBPC-Disruptive behavior. The other five cohort trials found no change in cognitive function after B12 treatment.

Interactions and Covariates. RCTs reached statistical significance less often than cohort studies. When they reported significant changes, RCTs usually implied an improvement of cognitive function. Significant changes for cohort studies were not consistent, some finding improvement, some decline of cognitive function scores. There is large heterogeneity among RCTs and cohort studies in terms of dose, route, and duration of treatment and it would be difficult to support any conclusion about a potential dose effect. However, the only significant changes in cognitive score were found when B12 was injected rather than given orally. Seal 2002 directly evaluated the effect of B12 oral supplementation in two intervention arms, one receiving double the dose of the other, and compared these groups with placebo. No significant change was found when MMSE score differences of the three groups were compared. In the cohort study by Mitsuyama 1988 five of the 14 demented participants were orally supplemented with 2 mg B12 daily while nine subjects had an additional B12 injection of 0.5 mg. Only those receiving B12 injections showed an improvement from baseline in GBS (P value not reported).

I to 2001 analyzed the results based on the severity of dementia of Alzheimer's type. Both subjects with questionable or mild AD and participants with moderate or severe AD had non-significant improvement in MMSE after treatment. Abyad 2002 analyzed the results according to treatment duration for dementia before the trial. Both subjects with short-term treatment and subjects with long-term treatment improved MMSE; short-term treatment participants had a significant increase. Martin 1992 evaluated separately patients with cognitive impairment of long duration and patients with cognitive impairment of short duration. Only the subjects with disease of short duration showed a significant improvement in Mattis' DRS.

There was no evidence across studies of differences in effect on tests of different cognitive domains.

Summary. Five RCTs of narrow to moderate quality, one non-randomized comparative study, and seven cohort studies assessed the effect of vitamin B12 intervention on cognitive function in humans. All studies had narrow to moderate applicability. They evaluated populations that included normal participants, subjects with cognitive impairment, dementia, or AD. Several studies recruited only individuals with low B12 levels, however the definition for low B12 levels varied. There was large heterogeneity among studies in terms of dose and route of intervention as well as the cognitive function assessment instrument. Although several of the studies showed small changes in cognitive function, few reached statistical significance. Across studies that assessed similar populations after implementing the same test, results were conflicting. Several cohort studies revealed significant improvement while a smaller number of cohorts reported a significant decline in scores for cognitive function. However, the interpretation of these studies is difficult because they analyzed subjects who may have had variable courses of dementia over time, without using a control group for comparison. Vitamin B12 was given intramuscularly in the only RCT that found a significant effect in the treatment group compared to controls. Similarly, only cohort studies that used intravenous or intramuscular vitamin B12 reported a significant effect on cognitive function scores. However, given the lack of data directly comparing oral and injected routes of vitamin B12 and the paucity of controlled trials limits any conclusions regarding the utility of different routes of administration. There was very limited evidence whether other covariates may interact with B12 supplementation. Most studies did not take into consideration potential factors such as disease duration that may interfere with B12 effect.

##### Folate Intervention Studies

Study Descriptions. Three RCTs^65,^ ^79,^ ^80^ and two uncontrolled cohort studies^81,^ ^82^ reported data on folate supplementation and the effect on cognitive function or therapeutic benefit. Two studies were conducted among subjects with dementia, one among cognitive impaired, one among normal subjects, and the fifth among those with PD. All but one study included subjects whose mean ages were 60 years and above; the remaining study did not document mean age. The studies tested various doses of folic acid or folate ranging from 0.75 to 20 mg daily. These doses are all substantially larger than the US RDA of 0.4 to 1 mg per day. Study durations ranged from 5 to 17 weeks. The primary outcome for three studies was cognitive function measured with WAIS-R and/or other cognitive tests. One study also evaluated therapeutic benefit. About 130 subjects were tested in five studies. All studies were of moderate to poor quality (2 B, 3 C). Three studies have moderate, and two narrow applicability.

Overall Effect. Among the five studies that measured cognitive function in people with dementia, cognitive impairment, or no disease, one RCT found a trend towards worsening of neuropsychological scores in the folic acid treatment group, suggesting a negative benefit of high dose folate among subjects with dementia. Two other studies, one RCT and one uncontrolled cohort studies found statistically significant improvement with folic acid or folate treatment compared with placebo among demented, cognitive impaired, and normal subjects, but did not report any clinical benefit. The study of patients with PD found no therapeutic benefit.

Fioravanti 1997 compared the effects of folic acid intervention with placebo among cognitively impaired subjects who had serum folate levels below 3 ng/mL. Cognitive function was assessed using six components of the Randt Memory Test (RMT). Compared to baseline the folic acid treatment group showed significant improvement in Attention Efficiency score, one of the six components of RMT, after 60 days treatment. However comparison between folic acid and placebo groups showed significant changes in the actively treated group with improvement in four out of six cognitive components of RMT.

Bryan 2002 was a double blind, placebo controlled randomized trial conducted to assess the effect of vitamin supplementation and dietary intake among normal women. The study utilized a mixed factorial design with four treatment groups (B6, B12, folate, and placebo) and three age groups (younger, middle-aged, and older) to assess the effect on cognitive performance. Here we summarize the results from the subgroup of older women who were treated with a small dose of folate (0.75 mg). In post hoc comparisons of two measures of memory, Rey Auditory-Verbal Learning Test (RAVLT) immediate recall and recognition list, and verbal ability (verbal fluency-initial letter), older women in the folate treatment group identified significantly more words when compared to the placebo group. No significant effect was observed in other tests.

Sommer 2003, in a very small double blind RCT, compared 20 mg per day of folic acid to placebo in seven subjects who fulfilled the standard diagnostic criteria for dementia. There were small trends towards a negative effect on cognitive abilities with folic acid treatment in two of the cognitive tests, the Associated Learning subtest that measures verbal learning, and Trails B that measures perpetual motor speed.

Rapin 1988 recruited subjects with dementia and low red blood cell (RBC) folate levels. This study was an uncontrolled cohort study that treated dementia subjects with 50 mg per week of folinic acid for about 17 weeks. Treated subjects had a significantly improved performance in five of 16 cognitive tests. They also reported improved feeling of well-being.

The single study of patients with PD, by McGeer 1972, was a cohort study of 15 mg per day of folic acid among 18 subjects. The study found that the folic acid intervention provided slight to no therapeutic benefit assessed by subjective or objective change in PD symptoms.

Interactions and Covariates. The intervention trials did not provide adequate evidence to support any dose effect of folate on the outcomes. However, Fioravanti 1997 found that the cognitive improvement after folate intervention was correlated in a linear fashion with the low levels of folate at baseline. One RCT^80^ and one uncontrolled study^82^ studied the effect of folic acid intervention on cognitive function among subjects with low serum or RBC folate levels, and one RCT among those with normal folate levels.^79^. Two other studies did not provide data on blood folate levels before or after intervention. One RCT and one uncontrolled cohort study reported significant effects in the same cognitive domain.

Summary. A total of five studies of moderate to poor quality reported data on the effect of folate intervention among normal people or those with dementia, cognitive impairment, or PD. Overall, one RCT among subjects with dementia and normal folate levels found a trend towards worse performance in the cognitive function scores with folic acid intervention. Two studies, one RCT and one uncontrolled cohort study found statistically significant improvements in the cognitive scores in the actively treated groups among demented, cognitive impaired, and normal subjects and the last found no benefit among PD subjects. However, interpretation of the cohort studies is difficult without a comparable control group given the variable course of dementia over time. None of the studies provided data on clinically significant effect after the vitamin intervention.

##### Combined B Vitamins Intervention Studies

Study Descriptions. Six studies, including 3 RCTs^83^–^85^ and 3 uncontrolled cohort studies^86^–^88^ assessed the effects of a combination of B vitamins as interventions on cognitive function in elderly subjects. Four trials included subjects with AD and/or mixed dementia,^83,^ ^85,^ ^86,^ ^88^ one with cognitive impairment,^87^ and one without dementia.^84^ All studies used different daily doses of various B vitamins in the ranges of 0.8 to 15 mg folic acid or folate, 3 to 80 mg B6, and 0.1 to 2 mg B12; all substantially over the US RDA. Three used a combination of folic acid, B6, and B12, two used folic acid and B12, and one used folate and B12. All but one study treated subjects with oral vitamin supplementation; Shaw 1971 used a combination of B12 injection and oral folate. All studies included subjects whose mean ages were greater than 70 years. The primary outcome for all studies was cognitive function. About 470 subjects were tested in six studies. All studies were of moderate to poor quality (2 B, 4 C). One study has broad applicability, four moderate, and two narrow applicability.

Overall Effect. Five of the six studies found no significant change in cognitive function, generally measured with MMSE or WAIS, after combination B vitamin supplementation.

The single study to find a significant improvement, Nilsson 2001, was an uncontrolled cohort study. This study found significant changes in the cognitive score performance among subjects with mild-moderate dementia and elevated plasma homocysteine concentration with a significant global clinical improvement after vitamin intervention. There was a four point increase in the mean MMSE score from a baseline score of 17. However the same study failed to show any improvement among patients with severe dementia or those with mild-moderate dementia and normal plasma homocysteine levels with a mean baseline score of 21 after combined vitamin intervention.

Lewerin 2005, a RCT, compared moderate doses of vitamins supplementation to placebo among ambulatory normal subjects, and measured cognitive function with a battery of nine tests. The placebo arm performed better in three of the tests compared to the actively treated group. Two other RCTs reported no significant changes in cognitive function in either intervention arms after vitamin supplementation. The remaining two cohort studies, Aisen 2003 and Lehmann 2003, reported no observable differences after treatment.

Interactions and Covariates. There was no dose related responses discussed in the studies. Only Nilsson 2001, an uncontrolled cohort study reported a difference in cognitive function with relation to severity of dementia, and with the levels of plasma homocysteine (<2.69 versus >2.69 mg/L) after combined B vitamin intervention. This study also reported a significant improvement in alertness, orientation in time and space, recent memory and fewer clinical fluctuations among subjects with dementia after combined vitamin intervention. One RCT^85^ used a combination of B12 injection and oral folate among senile dementia with high and low RBC folate levels; remainder of the studies evaluated combined vitamin intervention among those with normal blood vitamin levels. There was no evidence across studies of differences in effect on tests of different cognitive domains.

Summary. Six studies of moderate to poor quality reported data on the effect of combined B vitamin intervention among normal people, cognitively impaired, and those with AD and/or mixed dementia. The three RCTs found no benefit in the actively treated arm compared to placebo. Only one of the uncontrolled cohort studies found both statistically and clinically significant large benefit. However, interpretation of the cohort studies is difficult without a comparable control group given the variable course of dementia over time. The two other uncontrolled cohort studies reported no benefit after intervention.

#### Association of Dietary Intake Levels of B Vitamins to Age-Related Neurodegenerative Diseases

In this section, we summarize the findings from five (retrospective and prospective) longitudinal studies^89^–^91^ and five cross-sectional studies^65,^ ^92^–^96^ that examined the association between the dietary intake levels of B vitamins and cognitive function or the risk of age-related neurodegenerative diseases. We included all populations from longitudinal studies, while only non-institutionalized or free-living populations were included from cross-sectional studies in order to assess their “usual” dietary intake levels. All dietary assessment methods have certain strengths and limitations; thus it is important to choose an appropriate method depending on the study design and research questions.^97^ For example, a food record or diet recall is appropriate for estimating the mean dietary intakes in the study population. Food frequency questionnaire (FFQ) is a semi-quantitative instrument and it is designed to estimate the long-term usual intake. FFQ is good for ranking subjects' intake levels, but might not be appropriate for estimating the mean dietary intake levels.

##### Longitudinal Studies

Study Descriptions. One prospective nested case-control study, three prospective cohort studies, and one retrospective case-control study examined the association between dietary intake levels of B vitamins and neurodegenerative diseases or cognitive function (Tables 15–17). Each study associated the B vitamin intake levels with different outcomes, including the risk of newly developed PD cases, rates of cognitive change per year, follow-up cognitive function examined by various cognitive tests, and a diagnosis of probable AD. Two studies were of good quality, one study was of moderate quality, and the other two studies were of poor quality.

Table 15 Association between dietary intake levels of vitamin B6 and neurodegenerative diseases or cognitive function in longitudinal studies

[table image]

Table 16 Association between dietary intake levels of vitamin B12 and neurodegenerative diseases or cognitive function in longitudinal studies

[table image]

Table 17 Association between dietary intake levels of folate and neurodegenerative diseases or cognitive function in longitudinal studies

[table image]

Overall Effects. Chen 2004 conducted a nested case-control study to investigate whether intake of folate or related B vitamins involved in folate and homocysteine metabolism was associated with PD risk, using two large cohorts in the US - the Health Professionals Follow-up study (1986-2000) and the Nurse's Health Study (1980-1998).^89^ The two cohorts were analyzed separately and then pooled analyses were also performed. Participants' dietary intakes were assessed by a food frequency questionnaire during the previous 12 months. It was found that controlling for age, smoking, alcohol consumption, caffeine intake and lactose intake, there were no significant associations found between the baseline intake of folate, vitamin B6, or vitamin B12 and relative risk of PD in either study. Several sensitivity analyses were also performed for different levels of folate intake. Individuals at either the low end (≤200 μg/day) or the high end (>1000 μg/day) of folate intake had a PD risk similar to that of people with normal folate intake, controlling for various possible confounders. Furthermore, in a separate analysis, supplemental intake of folate, vitamin B6, or vitamin B12 was also not related to the risk of PD. Compared with non-supplemented participants, individuals whose supplemental folate intake was more than 400 μg per day had a pooled RR of 1.0.

Morris 2005 conducted a prospective longitudinal cohort study to examine the associations of dietary folate and vitamin B12 with 6-year cognitive change in the participants of the Chicago Health and Aging Project.^98^ Change in cognitive function measured at baseline, 3-year and 6-year follow-ups, using the average z score of four tests: the East Boston Tests of immediate and delayed recall, the Mini-Mental State Examination, and the Symbol Digit Modalities Test. The median dietary intake of folate ranged from 175 to 382 μg/day for first and last quintile respectively. The median intake of folate, from food and supplements, ranged from 186 to 742 μg/day for first and last quintile respectively. At baseline, it was found that persons with high intake of total folate (from food and supplements) tended to have a more favorable risk profile for cognitive change (more years of education, higher baseline cognitive scores, and greater consumption of vitamin E and vitamin C) than persons with low intake. After a median follow-up of 5.5 years, unexpectedly, high folate intake from food sources and/or supplements was associated with a faster rate of cognitive decline in a mixed models adjusted for multiple risk factors. Further sensitivity analyses showed no change in the effect estimates after restricting the analyses in persons who reported poor health status or with low baseline cognitive scores (bottom 15% of the distribution) at baseline. Intake of vitamin B12, with or without vitamin supplementation, was not significantly associated with cognitive change in the multivariate model or with adjustment for folate intake (data not shown).

Part of Tucker 2005 study examined the association between dietary B6, B12 and folate intakes and 3-year changes in cognitive measures in the Veterans Affairs Normative Aging, a longitudinal cohort consists of 321 aging men at baseline.^96^ Cognitive function was assessed with the MMSE and on the basis of measures of memory, verbal fluency, and constructional praxis, which were adapted from the revised WAIS and the CERAD batteries at 2 time points. Improbable dietary intakes (total energy >16.75 or <2.51 MJ) were excluded from further analysis. Over a mean 3-year follow-up, changes in constructional praxis measured by spatial copying were significantly associated with dietary folate, B6 and B12. The mean dietary folate, B6 and B12 was 440 μg/day, 3.98 mg/day and 9.57 μg/day, respectively. Dietary folate remained independently protective against a decline in spatial copying score after adjustment for other vitamins and for plasma homocysteine. Dietary folate was also protective against a decline in verbal fluency. There was no other significant association found between dietary folate, B6, or B12 and changes in other cognitive measures. The major limitation of these analyses is that dependent biases might occur, since the dietary intakes and cognitive measures were both assessed by self-administered instruments.

Deijen 2003 conducted a prospective cohort study to examine the relation between nutritional intake and daily functioning in elderly people being evaluated in a psychogeriatric nursing home.^90^ During the study 60 percent of the dropouts “became ill” compared to 34 percent of the subjects who completed the study. Participants' dietary intakes were assessed by a combination of a 3-day record and weighing-back methods at baseline, weeks 8, 16 and 24, recorded by nurses. An analysis was performed to test for associations with change in ZIG-scores. Two experimental groups were formed based on high (>1.0 mg/day) and low intakes (≤1.0 mg/day) of B6 compared to their median intakes at baseline. There were no interactions between intake groups and week, indicating that the high and low intake groups had the same pattern of ZIG-scores across the 6-month experimental period. There was deterioration in cognitive, physical and social functioning with time. However, this study had several limitations. Dropouts had worse health status than completers; it is unclear whether the nurses who assessed exposure and outcomes were the same; and the restriction to nursing home residents limits applicability.

Mizrahi 2003 conducted a retrospective case-control study compared patients with AD to healthy controls. (Mizrahi, 2003 2188 /id} Both proxy and surrogate respondents of cases and controls were asked to recall their food consumptions using a food frequency questionnaire during three age periods: 20 to 39, 40 to 59 and 60 or more years old. It was found that those with AD had lower mean dietary vitamin B6 and folate intake compared to controls in the over 60 years of age period (P=0.05 and 0.01, respectively), but not in younger age periods. No statistically significant correlations were found between homocysteine levels and dietary vitamin B6 and folate intake in the three age periods for those with AD and controls. This study was deemed to be of poor quality due to serious recall biases. Specifically, controls might have had more accurate recalls than cases, because cases' intakes were estimated by proxy or surrogate respondents, and all respondents might remember the food consumption during more recent age period better than distant age periods. Finally, the recall periods were too long to obtain accurate food consumption data.

Summary. No significant associations were found between dietary intakes of B6 or B12 and PD, AD, cognitive functioning, or cognitive decline across three studies. One additional study found higher dietary intakes of B6, B12, and folate were associated with improvements in some, but not all, cognitive function measures. In three separate studies, folate intake was not associated with PD or AD; however, in one study, higher folate intake from food sources and/or supplements was associated with a faster rate of cognitive decline after adjusting for multiple risk factors.

##### Cross-Sectional Studies

Study Descriptions. Five cross-sectional studies examined the association between the dietary intake levels of B vitamins and cognitive function or the risk of age-related neurodegenerative disease.^65,^ ^92^–^95^ Of the five studies, three were of fair quality and two were of poor quality.

###### Overall Effects

Thiamine (B1). Three studies associated participants' dietary intake levels of thiamine to their cognitive function scores.^92,^ ^93,^ ^95^ One additional study compared the dietary intake levels of thiamine in participants with AD to that in normal participants (Table 18).^94^ No statistically significant association was found between the dietary intake levels of thiamine and cognitive function scores, except for Goodwin 1983 that found that participants who were in bottom 5 percent of thiamine intake levels had significantly worse Wechsler verbal memory test scores than those who were in the top 90 percent. Renvall 1989 found that participants with AD had similar dietary intake levels of thiamine as normal participants.

Table 18 Association between dietary intake of vitamin B1 (thiamine) and cognitive function in cross-sectional studies

[table image]

Riboflavin (B2). The same four studies that evaluated thiamine also assessed participants' dietary intake levels of vitamin B2 (Table 19).^92^–^95^ Similar results were found except that Goodwin 1983 found that participants who were in bottom 10 percent of vitamin B2 intake levels had significantly worse Wechsler verbal memory test scores than those who were in the top 90 percent. In addition, Lee 2001 found that, adjusting for age, the dietary intake levels of vitamin B2 increased with MMSE scores among women, but not among men.

Table 19 Association between dietary intake of vitamin B2 (riboflavin) and cognitive function in cross-sectional studies

[table image]

Pyridoxine (B6). Three studies associated participants' dietary intake levels of vitamin B6 with cognitive function scores (Table 20).^65,^ ^92,^ ^95^ No statistically significant association was found between the dietary intake levels of vitamin B6 and cognitive function scores, except for Goodwin 1983, which found that participants who were in bottom 10 percent, but not the bottom 5 percent, of B6 intake levels had significantly worse Wechsler verbal memory test scores than those who were in the top 90 percent.

Table 20 Association between dietary intake of vitamin B6 (pyridoxine) and cognitive function in cross-sectional studies

[table image]

Cyanocobalamin (B12). Three studies associated participants' dietary intake levels of vitamin B12 to their cognitive function scores (Table 21).^65,^ ^92,^ ^95^ One additional study compared the dietary intake levels of vitamin B12 in participants with AD to that in normal participants.^94^ No statistically significant association was found between the dietary intake levels of vitamin B12 and cognitive function scores or AD.

Table 21 Association between dietary intake of vitamin B12 and cognitive function in cross-sectional studies

[table image]

Folate. The same four studies that evaluated vitamin B12 intake also tested folate intake (Table 22)^65,^ ^92,^ ^94,^ ^95^ No statistically significant association was found between the dietary intake levels of folate and cognitive function scores, except for Goodwin 1983 that found that participants who were in bottom 5 percent of folate intake levels had significantly worse Wechsler verbal memory test scores than those who were in the top 90 percent. Renvall 1989 found that participants with AD had similar dietary intake levels of folate as normal participants.

Table 22 Association between dietary intake of folate and cognitive function in cross-sectional studies

[table image]

Summary. Among the five studies, only two found any significant associations between vitamin B intake and cognitive function scores. One study found that subjects with low intake of vitamins B1, B2, B6, and folate, but not vitamin B12, scored significantly worse on verbal memory than those with relatively high intake levels. One study also found association between vitamin B2 intake and MMSE score in women, but not in men. No association between dietary intake of B12 and cognitive function or diagnosis of AD was found in all five studies.

#### Association of Tissue Levels of B Vitamins to Age-Related Neurodegenerative Diseases

##### Thiamine (Vitamin B1) Level Association Studies

Study Descriptions. Eight cross-sectional studies examined the association of thiamine levels with diagnosis or cognitive function.^99^–^106^ Four of these studies measured serum, plasma, and RBC levels of thiamine among AD, non-AD, PD, and cognitively impaired subjects (Table 23). Four other studies reported the plasma, cerebrospinal fluid (CSF), and brain levels of thiamine diphosphate (TDP), the active form of thiamine in the brain (Table 24). The sample size for the cross-sectional studies ranged from 34 to 290. The two studies by Mastrogiacoma 1996 and Molina 2002, which reported brain or CSF levels of thiamine derivatives (free thiamine, total thiamine, thiamine monophosphate, thiamine diphosphate), compared the levels between AD and normal controls. Jimenez-Jimenez 1999 compared the CSF levels of thiamine derivatives between PD and controls. Snowdon 2000 compared the thiamine levels from stored blood within a subset of AD subjects who had histologically significant and non-significant lesions in the brain at autopsy. All studies were graded moderate to poor quality (3 B, 5 C). Three studies have broad applicability, two moderate, and three narrow applicability.

Table 23 Association of thiamine (vitamin B1) levels and prevalence of thiamine deficiency with cognitive function

[table image]

Table 24 Association of levels of thiamine or thiamine derivatives (vitamin B1) with diagnoses of age related neurocognitive disorders

[table image]

Overall Effect. Four studies evaluated plasma and/or RBC thiamine or thiamine pyrophosphate (TPP), two of which found significantly greater deficiency among AD subjects compared to PD or controls (Table 23). Four other studies evaluated thiamine or thiamine derivatives in CSF, plasma, and cerebral cortex (Table 24). Two of these reported significantly reduced levels of thiamine derivatives in plasma or cerebral cortex among AD subjects and one among subjects with PD.

Gold 1995 examined the thiamine levels in the plasma and RBCs and found significantly low plasma thiamine levels and a high prevalence of plasma thiamine deficiency, but not for RBC thiamine, among probable AD, compared to non-AD subjects. A subsequent publication by the same author (Gold 1998) evaluated thiamine levels in the plasma and RBC thiamine among AD and PD subjects, and reported similar significantly lower levels and higher prevalence of plasma thiamine among AD subjects. The plasma level of thiamine among PD subjects was normal. Assantachai 1997 estimated serum levels and reported a high, but non-significant prevalence of thiamine deficiency among cognitively impaired compared to normal elderly subjects. Scillepi 1984 reported normal mean thiamine levels among AD and non-AD subjects.

Jimenez-Jimenez 1999 compared CSF levels of thiamine and its phosphate esters among PD patients and normal controls. All thiamine derivatives in the CSF except free thiamine were normal among PD patients. Molina 2002 compared subjects with AD to normal controls. This study examined CSF and plasma levels of thiamine derivatives and reported significantly lower plasma levels of thiamine derivatives among AD subjects. Among a subset of AD patients annual mean decreases in MMSE score was assessed and there were no significant differences in mean MMSE scores with high versus low thiamine levels. Mastrogiacoma 1996 examined thiamine derivatives in autopsied cerebral cortex among AD and normal subjects. The mean levels of TDP in the temporal, parietal, occipital areas of cerebral cortex were slightly, but significantly reduced by 18 to 21 percent among AD subjects compared to normal subjects. The levels of other thiamine derivatives were normal among AD subjects. Snowdon 2000 described a negative, but non-significant correlation of serum thiamine levels with severity of cerebral cortex atrophy among AD subjects with histologically significant lesions. AD subjects with histologically non-significant lesions had a positive, but non-significant correlation of serum thiamine levels with severity of atrophy of the cerebral cortex.

Interactions and Covariates. Gold 1998 (Table 23) performed secondary analyses excluding four PD patients less than 60 years of age, matching the two groups for age. They found significant differences in both the plasma thiamine levels and the prevalence of thiamine deficiency (defined as plasma or RBC thiamine values below the range of normal for their respective age group) between AD, and PD subjects. Snowdon 2000 (Table 24) adjusted age as a potential confounder in the correlation analyses, but other studies did not adjust for potential confounders. No longitudinal studies evaluated the association of thiamine and cognitive function.

Table 25 Association of riboflavin (vitamin B2) levels with diagnosis of neurocognitive disorders

[table image]

Summary. Overall, eight cross-sectional studies evaluated levels of thiamine among AD, cognitively impaired and PD patients. Three studies reported significantly reduced mean thiamine or TDP levels in the plasma and brain among AD subjects, and one reported similar reduction in mean levels of thiamine derivative among PD subjects. None of the studies that showed significant results adjusted for potential confounders. The remaining four studies found no differences between the investigated groups.

##### Riboflavin (Vitamin B2) Level Association Studies

Study Descriptions. Two studies ^106,^ ^107^ reported cross-sectional data on riboflavin (B2) levels among AD, PD, and dementia subjects. One study compared blood levels of B2 in AD with control subjects, and the other compared plasma levels of B2 in PD with dementia subjects. Scileppi 1984 assessed blood levels of 12 vitamins among 55 AD subjects. The control group included a total of 58 normal, depressed, vascular and mixed dementia subjects. Coimbra 2003 assessed plasma levels of B2 among 31 PD subjects compared with 10 dementia subjects without stroke. These studies were assessed to be of poor quality (C) and moderate applicability.

Overall Effect. Scileppi 1984 reported no significant differences in the riboflavin levels between AD and the control groups. Coimbra 2003 found a mean plasma B2 level below normal among PD subjects, which was significantly lower than among subjects with dementia. Neither study adjusted for any confounders.

Summary. Two poor quality studies assessed the cross-sectional levels of riboflavin among AD, PD, dementia, and other control groups. One study reported no significant difference between AD and control subjects. The second reported lower plasma levels among PD subjects with a significant difference between PD and dementia subjects.

##### Vitamin B6 Level Association Studies

Study Descriptions. Ten studies examined the association of vitamin B6 serum levels with the diagnosis of dementia or cognitive impairment, and cognitive function, including three prospective longitudinal studies, one case control study, one retrospective cohort study, and five cross-sectional studies.^18,^ ^105^–^111^ Pyridoxal-5′-phosphate (PLP), an active coenzyme form of B6, was used to estimate B6 serum levels in all but two studies; one did not report the method for estimating B6^111^ and another study used a protozoological assay.^105^ The longitudinal studies recruited 313 to 1,092 participants, the case control study 80 subjects while the sample size for the other studies ranged from 30 to 127. Studies had narrow to broad applicability. Two of the longitudinal studies, the case control study and the retrospective cohort were of moderate quality (B) while the third longitudinal study and the five cross-sectional studies were of low quality (C).

One longitudinal study recruited participants with normal cognitive function and investigated whether low baseline levels for vitamin B6 may be a risk factor for cognitive decline after about 3 years of follow-up (Table 26).^112^ Cognitive decline was defined as 7 year cognitive change with at least a 9-point drop of the total cognitive score (the sum of all subtest scores). Another longitudinal study also recruited participants with normal cognitive function and tried to correlate cognitive function after almost 8 years of follow-up with the baseline levels of vitamin B6 (Table 26).^96^ Cognitive function in this study was assessed by MMSE score, as well as by tests on construction praxis, language, working and recall memory. In the third longitudinal study, subjects with normal cognitive function were followed for a median of 8 years and new cases of AD or dementia were recorded (Table 26).^18^ The case control study compared the number of subjects with low PLP among patients with AD with that among individuals with intact cognitive function.^109^ The retrospective cohort study correlated the number of lesions in autopsies of women with AD with B6 levels^105^ while the rest of cross-sectional studies compared the mean B6 serum levels between different groups of participants, one comparing patients with AD, persons cognitively impaired but not demented, and normal participants; another study compared patients with AD and patients with other dementias; another comparing patients with AD and normal individuals; and the other two comparing patients with PD to patients with dementia, or to normal subjects (Table 27).

Table 26 Association of serum PLP level with diagnosis of AD, dementia, cognitive decline and cognitive function status in longitudinal studies

[table image]

Table 27 Association of serum PLP level with diagnosis of AD, cognitive impairment, dementia, and PD in retrospective cohorts, case-control, and cross-sectional studies

[table image]

Overall Effect. Seshadri 2002, in the longitudinal study, reported that B6 serum levels were not correlated with the risk of AD or other dementias after adjusting for age, sex, and ApoE genotype; although specific results were not provided. Kado 2005 did not find any significant increase in the risk for cognitive decline for participants with very low vitamin B6 levels after adjusting for age, sex, education, baseline cognitive function, baseline physical function, and smoking. However, Tucker 2005, after adjusting for baseline cognitive measures, age, education, smoking, alcohol intake, BMI, diabetes, systolic blood pressure, time of second measure relative to folic acid fortification, time interval between the two cognitive measures, and serum creatinine, reported a significant correlation between higher levels of vitamin B6 at baseline and better performance in the figure copying test after 3 years of follow-up (β=0.38, P <0.05). No other significant association was described in the same study between vitamin B6 levels and the score of other cognitive tests.

None of the cross-sectional studies found any significant correlation between B6 levels and diagnosis of AD or number of AD lesions in brain autopsy, cognitive impairment, or dementia. In addition, two cross-sectional studies found no association between B6 level and diagnosis of PD, compared to either people with dementia or normal people.

Interactions and Covariates. Generally, results were non-significant irrespective of the study design. Woitalla 2004 examined the association of B6 levels and diagnosis of PD in patients with different MTHFR genotypes (CC, CT, TT). No significant difference was reported when the three genotype groups were compared to each other or to the non-PD participants. There was no evidence across studies of differences in association with tests of different cognitive domains.

Summary. Three prospective longitudinal studies, one case control study, one retrospective cohort, and five cross-sectional studies examined the potential correlation of B6 serum levels with the diagnosis of dementia or cognitive impairment, and cognitive function. The studies were generally of low quality and had narrow to broad applicability. Only one of the longitudinal studies described a significant correlation between higher levels of vitamin B6 at baseline and better performance in the figure copying test after 3 years of follow-up. However, a similar association was not found for other cognitive tests that were assessed in the same study. It is uncertain whether the improvement in performance in the figure copying test is clinically important. Additionally, no statistically significant correlations were reported between B6 levels and AD or number of AD lesions in brain autopsy, cognitive impairment, PD, or dementia. There is very limited, low quality evidence to allow conclusion for any association between B6 levels and prevention or regression of cognitive function decline.

##### Cobalamin (Vitamin B12) Level Association Studies

Study Descriptions. Seven longitudinal studies examined the potential association of serum B12 levels with the risk for developing dementia, AD, or cognitive decline (Table 28).^18,^ ^25,^ ^96,^ ^112^–^115^ Two of the longitudinal studies recruited participants with normal cognitive function and tried to correlate cognitive function after 3 and 8 years of follow-up to the baseline levels of vitamin B12.^96,^ ^114^ Cognitive function in these two studies was assessed by MMSE score, as well as by tests on construction praxis, language, working and recall memory, and visual reproduction. Sample size ranged between 234 and 1092 among the studies. Six studies included cognitively intact subjects while the seventh also recruited patients with AD. Follow-up ranged between 20 months and 8 years. Studies were generally of moderate quality (5 B, 2 C) and broad applicability.

Table 28 Association of serum vitamin B12 levels with diagnosis of AD, dementia, or cognitive decline in longitudinal studies

[table image]

Four cross-sectional studies assessed the potential association between B12 serum levels and cognitive function (Table 29).^83,^ ^116^–^118^ Sample size ranged from 127 to 680. One study included patients with AD and frontotemporal dementia, another study had patients with PD and normal individuals while two studies recruited only subjects with AD. All studies implemented MMSE to assess cognitive function. In addition one study used ADAS test while another used Mattis' DRS. Studies were of low to moderate quality (2 B, 2 C) and narrow to broad applicability.

Table 29 Association of serum vitamin B12 levels with cognitive function in cross-sectional studies

[table image]

There were 22 additional studies that compared the B12 serum levels between different groups of participants.^99,^ ^106,^ ^107,^ ^111,^ ^119^–^136^ Two of the longitudinal studies also compared mean B12 levels with AD diagnosis and cognitive function at baseline.^25,^ ^113^ Five studies estimated the odds ratio for AD or cognitive impairment at certain B12 serum levels (Table 30).^120,^ ^121,^ ^123,^ ^127,^ ^130^ Nine studies compared the percentage of participants with low serum B12 level among different groups including subjects with dementia, cognitive impairment, AD, vascular dementia, and cognitively intact individuals (Table 31).^25,^ ^119,^ ^121,^ ^122,^ ^124,^ ^125,^ ^129,^ ^133,^ ^134^ Definitions of low B12 level varied among studies, ranging from ≤139 mg/mL to <340.1 mg/mL. In addition, 19 studies compared the mean B12 serum levels between different groups of participants, such as subjects with dementia, cognitive impairment, AD, senile and vascular dementia, PD, and cognitively intact individuals (Table 32).^99,^ ^106,^ ^107,^ ^111,^ ^113,^ ^120,^ ^122^–^132,^ ^134,^ ^135^ Sample size ranged from 41 to 939. All studies measured serum B12 levels except for one study that reported also CSF B12 levels.^124^ Studies were of low to moderate quality (1 A, 7 B, 14 C) and narrow to broad applicability.

Table 30 Studies reporting odds ratio (OR) or risk ratio (RR) for diagnosis of AD or cognitive impairment at threshold vitamin B12 serum levels

[table image]

Table 31 Studies reporting prevalence of subjects with threshold serum vitamin B12 levels among those with dementia diagnoses

[table image]

Table 32 Association of serum and CSF vitamin B12 levels with diagnoses of dementias in cross-sectional studies

[table image]

Overall Effect. None of the longitudinal studies showed any significant correlation between serum B12 levels and the risk for developing AD or dementia. However, Tucker 2005, after adjusting for baseline cognitive measures, age, education, smoking, alcohol intake, BMI, diabetes, systolic blood pressure, time of second measure relative to folic acid fortification, time interval between the two cognitive measures, and serum creatinine, reported a significant correlation between higher levels of vitamin B12 at baseline and better performance in the figure copying test after 3 years of follow-up (β=0.56, P <0.05). Similarly, Elias 2005, after adjusting for age, education, and gender as well as for Framingham stroke risk profile score, creatinine, alcohol consumption, coffee consumption, total cholesterol, BMI, and ApoE genotype described a significant correlation between higher levels of vitamin B12 at baseline and better performance in the global composite score for cognitive function after almost 8 years of follow-up (β=0.002, P <0.05). This study also reported significant correlation for immediate and delayed recall in the visual reproduction test (β=0.04, P<0.02 and β=0.04, P<0.03 respectively).

Among the other studies that evaluated cognitive function, no significant correlation was found between B12 serum levels and cognitive function test scores for any of the populations included. Among the studies that estimated OR, only Argyriadou 2001 found that the odds for low B12 serum level is two-fold higher in subjects with MMSE score low enough to show cognitive impairment than in cognitively intact individuals (P=0.03). The cutoff level for low B12 in this paper was <145 mg/mL. There were two more studies, which did not estimate an OR, but reported that significantly more subjects with AD or cognitively impaired presented with low serum B12 levels. Tripathi 2001 compared patients with AD and low B12 levels (<187 mg/mL) and subjects with other types of dementia (P<0.05) while Shahar 2001 compared cognitively impaired subjects presenting with lower B12 levels (<203 mg/mL) and cognitively impaired subjects with higher B12 levels (one group with B12 levels 150 to 250 mg/mL and another with greater than 250 mg/mL) (P=0.04 after adjusting for age).

Clarke 1998 compared mean serum B12 levels between patients with AD and cognitively intact participants and found no significant difference. However, when the same study was restricted only to the population with a histological diagnosis of AD, it found that significantly lower serum B12 levels were measured compared to the normal population (P<0.05). A subgroup of the participants in the same study, including 51 subjects with histological diagnosis of AD and 65 normal participants, was evaluated in a later publication by Refsum 2003. Serum holotranscobalamin levels, an active part of total serum B12, were measured and were found to be significantly lower in patients with AD than in controls (P<0.001).

Postiglione 2001 also found significantly lower B12 levels in patients with AD compared to normal individuals but the difference was not significant when the analysis was adjusted for age, serum creatinine, and duration of AD. In addition Religa 2003 reported significantly lower serum B12 levels in the AD group compared to cognitively intact participants (P<0.05). In the same study, no significant difference was reported when subjects with mild cognitive impairment were compared with the normal population. Tripathi 2001 also compared subjects with AD and patients with other dementias and found that the AD population presented with significantly lower B12 levels. In contrast Regland 1988 found that mean vitamin B12 levels for AD and cognitively intact groups were normal while the senile dementia group had a significantly lower B12 level (P=0.0002). None of the other studies including populations with AD or cognitive impairment supported any significant differences for B12 levels. Studies with subjects presenting with PD and vascular dementia did not report any significant results.

Interactions and Covariates. Prospective longitudinal studies reached statistical significance less often than cross-sectional studies. When they reported significant associations, both longitudinal and cross-sectional studies usually found that better cognitive function was related to higher vitamin B12 levels. Assantachai 1997 found that patients with AD and ApoE ε4 genotype had significantly lower B12 levels than patients with vascular dementia and ApoE ε4 genotype, while AD patients with other genotypes had similar B12 levels as those with vascular dementia.

Woitalla 2004 examined the correlation of B12 levels and diagnosis of PD in patients with different MTHFR C677T genotypes (CC, CT, TT). No significant difference was reported when the three genotype groups were compared to each other or to the non-PD participants. McCaddon 2004 found that holotranscobalamin was significantly higher in CC genotypes than the heterozygous CG genotype (P=0.04). Postiglione 2001 also found non-significant differences in B12 levels when they analyzed subcategories of AD patients or controls who were homozygous for MTHFR C677T or non-homozygous.

Postiglione 2001 also reported a statistically significant correlation between duration of disease in months and B12 (r = -0.460, P<0.05), supporting a decrease in B12 vitamin levels with longer AD duration. Anello 2004 reported that B12 levels were not influenced by other covariates such as the severity of dementia or age of onset of the disease. Refsum 2003 showed that low holotranscobalamin was associated with AD at high total homocysteine concentrations (OR 9.45), but not at low homocysteine concentrations.

There was no evidence across studies of differences in association with tests of different cognitive domains.

Summary. Thirty-three studies of low to moderate quality and narrow to broad applicability investigated a potential association between serum or CSF vitamin B12 levels and cognitive function, or diagnosis of several types of dementia and cognitive impairment. Most of the studies focused on AD. The threshold values to define low B12 levels varied across studies. Based on the very few longitudinal studies, vitamin B12 levels did not affect the risk for developing AD or dementia. However, one of the longitudinal studies reported a significant correlation between higher levels of vitamin B12 at baseline among cognitively intact subjects and better performance in the figure copying test after 3 years of follow-up. Another longitudinal study also described a similar correlation for the global composite score for cognitive function and the immediate and delayed recall in the visual reproduction test after almost 8 years of follow-up. However, the clinical importance of these results is unclear. The existing evidence from other studies, which implemented a cognitive function assessment instrument, did not support any correlation between vitamin B12 levels and cognitive function. Among cross-sectional studies, there was a trend for vitamin B12 levels to be lower in patients with AD or other types of dementia, which in certain studies reached statistical significance. However, this trend was not consistent. An inverse correlation between vitamin B12 levels and duration of AD was reported by one study. Besides that evidence for patients with AD or cognitive impairment, there was very limited evidence for populations with PD, and vascular dementia. Potential factors such as genetic mutations, or disease severity that may affect vitamin B12 levels were analyzed by few studies without a consistent effect. Considering also that most of the studies were cross-sectional, no causal relation between B12 vitamin and the developing or progression of dementia can be established.

##### Folate Level Association Studies

Study Descriptions. A total of 34 studies examined the role of folate vitamin levels with the diagnoses of age related neurocognitive disorder or with cognitive function. Twenty-three studies examined the mean folate level with cognitive function or PD,^83,^ ^99,^ ^105^–^107,^ ^109,^ ^111,^ ^113,^ ^116,^ ^120,^ ^122^–^125,^ ^127^–^132,^ ^137^–^139^ 10 examined the prevalence of folate deficiency in normal and cognitively impaired or demented participants,^25,^ ^114,^ ^119,^ ^121,^ ^122,^ ^124,^ ^125,^ ^129,^ ^140,^ ^141^ and 15 assessed the risk of AD, dementia, and cognitive impairment with folate levels.^18,^ ^25,^ ^96,^ ^105,^ ^112^–^115,^ ^120,^ ^121,^ ^123,^ ^127,^ ^130,^ ^140,^ ^142^ Ten of the studies were longitudinal, examining the association between folate levels and future cognitive function; the remainders were case-control or cross-sectional with single time-point analyses (Table 33). The folate levels were assessed in the RBC, plasma, serum, CSF, and blood. The sample sizes of the studies ranged from 30 to 1,100. The majority of the studies were graded moderate to poor quality (1 A, 15 B, 18 C). Fifteen studies had broad, 17 moderate, and 2 narrow applicability.

Table 33 Association of mean folate levels with diagnosis of age-related neurodegenerative disease

[table image]

Overall Effect. All studies reported lower mean folate levels or higher prevalence of folate deficiency among subjects with AD, and cognitive impairment. Among studies that assessed the association between folate levels and cognitive function, four longitudinal studies and one case-control study reported a statistically significant association between lowest quantile of folate level and cognitive decline after adjusting for possible confounders. One other case-control study reported a significant inverse association of folate with cognitive function. Two studies reported folate levels within normal limits among PD subjects.

Fewer than one-third of the 23 studies that examined the mean folate levels and cognitive function reported significantly lower mean folate levels in AD compared with normal subjects (Table 33). Only two studies - Postiglione 2001 and Bowirrat 2002 - adjusted mean folate levels for possible confounders; they reported no significant differences in mean folate levels between AD and normal subjects.

All studies that examined the prevalence of folate deficiency compared subjects with AD or cognitively impairment with other types of dementia or normal subjects (Table 34). The range of prevalence of folate deficiency was between 0 and 67 percent. Across all studies, the prevalence of folate deficiency was higher among AD than controls. Only two studies, Joosten 1997 and Wang 2001 reported statistically significant prevalence of folate deficiency among AD subjects, and those with MMSE mean score ≤26, respectively.

Table 34 Prevalence of folate deficiency among subjects with dementia, cognitive impairment, and normal cognition

[table image]

Among 10 studies that examined the longitudinal decline of cognitive function (Table 35), Ravaglia 2005, Kado 2005, Tucker 2005, Maxwell 2002, and Clarke 1998 compared the lowest versus the highest quantile of folate. After adjusting for possible confounders, Ravaglia 2005, Kado 2005, and Tucker 2005 found an increased risk of cognitive function decline among those in the lowest quantile levels of folate. Tucker 2005 found independent effects of lowest folate level among men with mild cognitive impairment with longitudinal (mean of 3 year) and large decline in the score of constructional praxis (spatial copying). Maxwell 2002 examined the risk of adverse health outcomes including cognitive decline with association to the quartiles of folate during 5-year follow-up. This study noted that subjects with lowest folate levels were at greater risk for significant cognitive decline independent of possible confounders. In contrast, Seshadri 2002, Elias 2005 and four other longitudinal studies found no association between folate level and future cognitive function. Three case-control and one cross-sectional studies assessed the odds of AD in relation to high versus the low levels of folate, using a single time point analyses (Table 36). Of note, Quadri 2004 reported a consistently significant association of cognitive impairment with the lowest tertile of folate.

Table 35 Folate level as a predictor of cognitive function in longitudinal studies

[table image]

Table 36 Folate level as a predictor of cognitive function in case-control studies and cross sectional studies

[table image]

Snowdon 2000, a case-control study described a significant negative age-adjusted correlation of folate levels with severity of cerebral cortex atrophy among all AD subjects, as well as a subset of AD subjects with histologically significant cerebral cortex lesions at autopsy. The regression analysis adjusted for age and histological severity of AD found a 4.4 ng/mL decrease in serum folate was associated with a 1-point decrease for the MMSE score indicating a significant inverse association of folate with cognitive function.

Two studies reported folate levels in PD subjects (Table 33). Woitalla 2004 compared the mean folate level in PD with normal subjects. This study subdivided PD and normal subjects according to their methylene tetrahydrofolate reductase (MTHFR) genotypes CC, CT, TT. The folate levels did not differ between PD and normal subjects, but was significantly higher in the CT allele subgroup of PD compared with normal subjects. Coimbra 2003 reported folate levels within the normal range that did not differ between PD and dementia subjects.

Interactions and Covariates. About one-third of the studies reported associations of folate levels with cognitive function decline adjusted for possible confounders. Four longitudinal studies that adjusted for all possible confounders reported independent and statistically significant association between folate level and cognitive function. Across the studies, there was an association between folate level and global cognitive function. Only one study^96^ reported significant effect on one other cognitive domain.

Summary. There are 34 studies of moderate to poor quality that have examined the role of folate vitamin levels with the diagnoses of age related neurocognitive disorder or with cognitive function. Overall, the studies reported lower mean folate levels or higher prevalence of folate deficiency among AD and cognitive impaired subjects. One-third of the studies adjusted for possible confounders. Of note, four of the 10 longitudinal studies reported consistent and statistically significant association between folate level and cognitive function score. Two case-control studies reported greater risk of cognitive function decline with lower folate levels among AD subjects. Two studies reported mean folate levels within normal limits among PD subjects.

##### B Vitamin-Homocysteine Interaction With Cognitive Function

Testing the hypothesis of a potential effect of the interaction between homocysteine and B vitamins on cognitive function was not the primary purpose for this report. Consequently, studies that did not consider B vitamins as independent predictors of cognitive function and limited their analyses to homocysteine or the interaction of homocysteine and B vitamins only, were not included in our review.

It is well established that B vitamin status (mostly folate, B12, and possibly B6) is a major determinant of homocysteine level.^143^–^145^ Among elderly subjects in the Framingham study, for example, two-thirds of cases of high homocysteine were associated with at least one vitamin concentration below the 70^th^ percentile.^143^ In addition, studies have consistently found that homocysteine levels can be reduced with B vitamin treatment.^123^ Furthermore, numerous studies - including several evaluated in this review of B vitamins - have demonstrated an association between higher homocysteine levels and worsened cognitive function. ^18,^ ^96,^ ^114,^ ^115^ Elevated homocysteine levels putatively may cause cognitive decline through both neurotoxic and vasotoxic effects.^146^ Of note, almost all trials of combinations of B vitamins - and several interventions with individual B vitamins - were designed with the intent of lowering homocysteine levels. Among studies that reported data on associations between cognitive function and both B vitamins and homocysteine, most found that the association of homocysteine and cognitive function was statistically independent of B vitamin levels; thus homocysteine levels were predictive of cognitive function even after correction for B vitamin deficiency. This statistical independence was found in both cross-sectional studies ^84,^ ^110,^ ^128,^ ^141^ and longitudinal studies,^18,^ ^115^ but does not imply a biological independence. Several studies, both cross-sectional^112,^ ^147^ and longitudinal^96,^ ^114^ found evidence of interactions between homocysteine and either folate, B12, or combined folate, B6, and B12.

Interpretation of the relative effect of different homocysteine levels on any interactions between B vitamin status and cognitive function is more problematic. Given that homocysteine is associated with cognitive decline and that B vitamins affect homocysteine levels, it is hypothesized that much of the B vitamins' role in preventing cognitive decline is through their effect on maintaining low homocysteine levels and thus any associations between B vitamin status and cognitive function would not be expected to be independent of homocysteine level.

However, among the five longitudinal studies that analyzed potential interactions between homocysteine and B vitamins on their association with cognitive decline, the MacArthur Studies of Successful Aging (MSSA),^112^ the Conselice Study of Brain Aging (CSBA),^115^ and the Veterans Affairs Normative Aging Study (VANAS)^96^ each found that baseline serum folate level (and also dietary folate in VANAS) was significantly associated with various measures of cognitive decline, independent of homocysteine or vitamins B6 or B12. Each set of authors conclude that the independent contribution of low folate to cognitive impairment may affect the development of cognitive impairment through mechanisms other than homocysteine's direct neurotoxicity. Of note, VANAS found independent effects of folate only for constructional praxis (figure copying), while MSSA analyzed a summary cognitive score based on several tests and CSBA analyzed diagnosis of AD. In contrast, both the Framingham Study^18^ and the Framingham Offspring Study^114^ found no association between folate level and cognitive function.

### B Vitamin Adverse Events

To answer the question regarding adverse events we reviewed all 39 prospective human trials of B vitamin interventions that we retrieved for possible inclusion regarding effect of treatment on age-related neurocognitive disorders. Three of these articles had multiple studies or study arms, thus there were 43 separate cohorts of subjects who received specific B vitamin treatments. Eight of these studies were rejected from analyses above either because of inclusion of ineligible populations or reporting only on outcomes not of interest for the purpose of this review.

Among the 43 studies/cohorts, only 10 reported any information on adverse events (Table 37). Only two of these reported that any adverse events occurred.

Table 37 Reported adverse events in B vitamin intervention studies

Study, Year | Dose / Day | Population | Mean Age(yr) | Duration | Design | N | | Adverse Events
| | | | | | Tx | Cx
Thiamine (B1)
Meador, 1993 | 3 g | AD | 71 | 1 mo | Crossover | 17 | | None
Study 1
Meador, 1993 | 4–8 g | AD | 71 | 13mo^a^ | Crossover^b^ | 17 | | All tolerated doses up to 6 g/day well without any side effects 2 (of 7) subjects reported nausea and indigestion at doses of 7.0 and 7.5 g/day, but subsequently tolerated the same dosages in later months.
Study 2
Blass, 1988 | 3 g | AD | 72 | 3 mo | Crossover | 11 | | None
Mimori, 1996 | Fursultiamine 100 mg | AD | 72 | 12 wk | Cohort | 9 | | None
Riboflavin (B2) | | No studies
Pyridoxine (B6) | | No studies
Cobalamin (B12)
Ikeda, 1992 | 500μg 3x/wkIV | AD | 71 | 12 wk | Cohort | 10 | | None
Folate
Yukawa, 2001^c^ | 15 mg | Dementia | 56 | nd | Cohort | 36 | | None
McGeer, 1972 | 15 mg | PD | nd | 14–182 days^d^ | Cohort | 18 | | 1 buzzing in the ears, 1 jittery feeling, 1 sleeplessness. No mental changes, weight loss, or gastrointestinal symptoms.
Sommer, 2003 | 20 mg | Dementia | 77 | 10 wk | RCT | 5 | 6 | None
Pyridoxine (B6) + Folate
Vermeulen, 2005^e^ | B6: 5 mg | Healthy | 46 | 2 yr | RCT | 68 | 73 | None
| Folate:250mg
Cobalamin (B12) + Folate | | No studies
Pyridoxine (B6) + Cobalamin (B12) + Folate
Aisen, 2003 | B6: 50 mg | AD | 71 | 8 wk | Cohort | 63 | | None
| B12: 1 mg
| Folate:50mg

N, number of subjects; Tx, vitamin B treatment, Cx, control;

a 1 month each at various doses, including 1 month of placebo.

b Single cohort of subjects all changing doses in a set sequence.

c Study did not meet eligibility criteria for evaluation of effect of B vitamin treatments.

d Mean 45 days.

e Study did not meet eligibility criteria for evaluation of effect of B vitamin treatments.

Three articles reported on adverse events related to thiamine (B1) or thiamine derivative interventions in four studies;^61,^ ^62,^ ^64^ two additional studies did not report on adverse events. In three studies, there were no adverse events, among 37 subjects total who took either 3 g thiamine per day or fursultiamine 100 mg per day for 1 to 3 months. All included patients with AD. The fourth study, also of patients with AD, found that 17 subjects all tolerated well thiamine doses between 4 and 6 g per day a month at a time. Among a subset of 7 subjects who took higher doses up to 8 g per day, two reported nausea and indigestion at doses of 7.0 and 7.5 g per day, but subsequently tolerated the same dosages in later months.

The single intervention study of riboflavin (B2) did not report on adverse events.

None of 4 studies of pyridoxine (B6) reported on adverse events.

Among 18 studies of cobalamin (B12), only one reported on adverse events.^70^ In a 12 week study of a cohort of 10 patients with AD who were treated with intravenous mecobalamin 500 μg 3 times a week for 8 weeks, there were no side effects detected in laboratory tests and there were no patient complaints.

Three of eight studies of folate supplementation reported on adverse events.^79,^ ^81,^ ^148^ The three studies evaluated 59 subjects who took either 15 mg or 20 mg folate per day. The two studies of patients with dementia reported no adverse events over 10 weeks or an unreported duration. In a cohort study by McGeer 1972 of 18 patients with PD who were treated with 15 mg folate per day for 14 to 182 days, three reported minor symptoms of “buzzing in the ears,” “a jittery feeling,” or “sleeplessness.” No mental changes, weight loss, or gastrointestinal symptoms were reported by patients.

One 2 year randomized trial reported that combination B6 (5 mg per day) and B12 (250 mg per day) was well tolerated in 158 healthy subjects (siblings of patients with premature atherosclerotic disease).^149^

The two studies that evaluated combination B12 and folate did not report on adverse events.

One of three studies of combination B6, B12, and folate reported on adverse events.^86^ In a cohort study of 63 patients with AD who were treated with daily doses of 50 mg B6, 1 mg oral B12, and 50 mg folate, no adverse events were reported over 8 weeks.

Overall, in 10 studies that included 254 subjects taking B vitamin supplements (and 79 subjects taking placebo), two subjects with AD in one study reported mild gastrointestinal complaints with high dose thiamine, which they were later able to tolerate, and three patients with PD reported possibly neurological complaints with folate. No serious adverse events were reported.

General Vitamin B Safety. As noted in Table 38, the Institute of Medicine (IOM) concludes that there are no reports of adverse events for any of the evaluated B vitamins within the range of the RDA and up to the Upper Limit (UL); although they acknowledge that data on adverse events for all the vitamins are limited.

Table 38 Institute of Medicine Dietary Reference Intakes of B vitamins and adverse effects

Nutrient | Life Stage Group | RDA | UL^a^ | Adverse effects of excessive consumption
Thiamine | Males | (mg/d) | | No adverse effects from food or supplements have been reported. Because data on the adverse effects of thiamin are limited, caution may be warranted.
| ≥31 yr | 1.2 | ND
| Females
| ≥31 yr | 1.1 | ND
Riboflavin | Males | (mg/d) | | No adverse effects from food or supplements have been reported. Because data on the adverse effects of riboflavin are limited, caution may be warranted.
| ≥31 yr | 1.3 | ND
| Females | | ND
| ≥31 yr | 1.1 | ND
Vitamin B6 | Males | (mg/d) | | No adverse effects from food or supplements have been reported. Because data on the adverse effects of B6 are limited, caution may be warranted.
Comprises a group of 3 vitamers: pyridoxal, pyridoxine, pyridoxamine; and 5′-phosphate coenzymes of each vitamer | 31–50 yr | 1.3 | 100 | Sensory neuropathy has occurred from high intakes of supplemental forms.
| ≥50 yr | 1.7 | 100
| Females
| 31–50 yr | 1.3 | 100
| ≥50 yr | 1.5 | 100
Vitamin B12 | Males | (μg/d) | | No adverse effects from food or supplements have been reported. Because data on the adverse effects of B12 are limited, caution may be warranted.
Including its coenzymes methylcobalamin and adenosylcobalamin | ≥31 yr | 2.4 | ND
| Females
| ≥31 yr | 2.4 | ND
Folate | Males | (μg/d) | | Masks neurological complication in people with vitamin B12 deficiency.
Note: Given as dietary folate equivalents (DFE). 1 DFE = 1 μg food folate = 0.6 μg of folic acid from fortified food or as a supplement consumed with food. | ≥31 yr | 400 | 1000 | No adverse effects from food or supplements have been reported. Because data on the adverse effects of folate are limited, caution may be warranted.
| Females | | | The UL for folate applies to synthetic forms obtained from supplements and/or fortified foods.
| ≥31 yr | 400 | 1000

Derived from Institute of Medicine report accessed at www.iom.edu/Object.File/Master/7/296/0.pdf via www.nal.usda.gov/fnic/etext/000105.html (accessed July 27, 2005).

RDA = Recommended Daily Allowance; UL = Upper Limit.

a UL = The maximum level of daily nutrient intake that is likely to pose no risk of adverse effects. Unless otherwise specified, the UL represents total intake from food, water, and supplements. Due to lack of suitable data, ULs could not be established for thiamin, riboflavin, or vitamin B12. In the absence of ULs, extra caution may be warranted in consuming levels above recommended intakes.

With a few exceptions and caveats, review articles on the safety of the B vitamins have concluded that B vitamin supplementation is safe. An older review by Marks in 1989,^150^ concluded that for all the B vitamins, at levels of intake approximately equivalent to those found in a good mixed diet, vitamins are beneficial and show no adverse reactions. He concluded that safe doses for thiamine are at least 50 to 100 times the RDA (i.e., above 100 mg daily); safe doses for riboflavin are substantially above 100 times the RDA (also above 100 mg daily); safe doses for pyridoxine are up to 200 mg daily (over 100 times the RDA); safe doses for oral cyanocobalamin are as high as 30 mg daily (over 10,000 times the RDA); and safe doses for folic acid of 50 to 100 times the RDA (up to about 20 mg).

The primary safety concern raised regarding thiamine involves rare reports of anaphylaxis after single oral doses in the range of 5 to 10 g or intravenous doses.^150,^ ^151^ However, one reviewer, Snodgrass, in 1992 theorized, primarily based on animal studies, that high dose intravenous thiamine - generally used in patients suspected of having Wernicke's encephalopathy, in part to prevent seizures - may actually be causing seizures. However, as noted by Snodgrass, a large report of almost 1000 patients receiving intravenous thiamine rarely resulted in complications.^152^ Only one patient had a major adverse reaction (generalized pruritis).

We found no safety concerns related to riboflavin.

Long-term, high-dose pyridoxine is well known to cause a reversible neuropathy. A literature review in 1986 by Cohen et al. noted that adults receiving more than 500 mg per day are at risk for developing sensory neuropathy, while short-term courses or lower daily doses does not result in adverse neurological changes.^153^ However, as noted by both Marks and Snodgrass, there have been reports of neuropathy with doses as low as 200 mg per day. ^150,^ ^151^

Prior to the addition of carbidopa to L-dopa treatment for PD, it was frequently noted that pyridoxine supplementation resulted in a loss of the L-dopa effect, with an increase in Parkinsonian symptoms.^154^–^159^ This effect is due to inhibition of peripheral decarboxylation of L-dopa.^160^ However, use of peripheral decarboxylase inhibitors such as carbidopa with L-dopa blocks the drug interaction, such that the efficacy of the two drugs is unaffected by pyridoxine.^158^–^160^

We found no safety concerns related to cobalamin, either in oral or parenteral form.

A systematic review of the safety of folic acid supplements was performed by Campbell in 1996, prior to the policy of mandatory grain fortification in the US.^161^ Several potential safety issues were discussed including masking of thiamine deficiency, neurotoxicity, drug antagonism, reduced zinc absorption, and hypersensitivity. Folate repletion in B12 deficient individuals is well-known to post the anemic manifestations of pernicious anemia while allowing posterolateral spinal cord degeneration to progress. This effect is generally seen only with higher doses of folate (≥5 mg daily) and can be avoided by testing for B12 deficiency.^161,^ ^162^ The question of neurotoxicity has been tested in patients with PD as described above (McGeer 1972). Several case reports of increased frequency of seizures in epileptics have been reported with folate doses of 5 to 30 mg;^162^ although this possible effect may in part be due to interactions between folate and anti-convulsant drugs due to their effect on folate metabolism.^161^ However, no drugs used specifically for neurodegenerative disorders interfere with folate metabolism. Campbell also found a limited number of case reports describing hypersensitivity reactions to oral and parenteral folic acid, but concluded that the reactions were probably to contaminants in the folate formulations.

## Berries

In this section, we summarize the results from human and animal or in vitro studies of berries and/or the constituents in berries in relation to age-related neurodegenerative disorders. The four Key Questions to be answered are as follows:

1 What are the constituents in berries with beneficial nerve- and brain-related health effects (from in vitro, animal, and human studies)?
  a In what other food sources are these constituents found?
2 What is the evidence regarding mechanisms of action of berry constituents for preventing, decreasing the rate of progression of, or reversing the neurological changes associated with age-related neurodegenerative conditions, including Parkinson's or Alzheimer's disease?
3 What is the evidence that the constituents of berries can prevent, decrease the rate of progression of, or reverse the neurological changes associated with age-related neurodegenerative conditions, including Parkinson's or Alzheimer's disease in humans
  a Is the source, species, dose, composition, characteristics, or processing of berries and berry constituents related to the effect of the intervention?
4 What adverse events in humans have been reported in the literature for the constituents in berries?
  a Do the frequency of adverse events vary with source, dose, or other evaluated factors?

Findings are presented in the order of the Key Questions.

Searches of the MEDLINE^®^ and CAB Abstracts™ databases for human, animal, and in vitro studies yielded 4,633 citations. After screening of the titles and abstracts, 151 articles were retrieved for examination. We retrieved an additional 20 articles identified from review articles, study reference lists, and domain experts. One human study and 18 animal or in vitro studies (with 19 experiments) were included in this review. Of note, 16 (89%) of these studies have been conducted by a single group of investigators at the Jean Mayer USDA Human Nutrition Research Center on Aging at Tufts University both with and without the cooperation of other research centers.

Qualifying studies are presented in summary tables in the appropriate sections. Details regarding all included studies are available in the evidence tables^*^.

### Constituents in Berries

Berries are generally high in fiber and some species may be high in vitamin C. Folate is the major B vitamin in some berries, although it does not contribute a substantial amount to a typical diet compared to other food items (Table 39). Complete nutrient contents of berries can be found in the USDA National Nutrient Database for Standard Reference (www.nal.usda.gov/fnic/foodcomp/search/). Like other fruits or vegetables, berries also contain various phytochemicals or phytonutrients, which might have antioxidant or anti-inflammatory effects. Flavonoids are believed to be the main antioxidants in berries. The flavonoid contents of various berries can be accessed in the USDA database for the “Flavonoid Contents of Selected Foods.”^163^ Currently, there is no standard nutrient database for other phytochemicals in fruit and vegetables. Research has derived some composition data on the anthocyanins and phenolics contents in diverse small fruits, including berries.^164,^ ^165^ Of the three included studies that evaluate the effects of the constituents in berries, only a limited number of the numerous constituents in berries have been examined. These included tannins (procyanidin and prodelphinidin), anthocyanin and phenolics, from various berries.

Table 39 USDA nutritional facts on selected raw berries (1 cup)^a^

Fresh fruit | Weight | Fat | Protein | Fiber | Sugar | VitaminA | VitaminC | Potassium | Thiamine | Riboflavin | VitaminB6 | Folate
Blackberries | 144 g | 1 g | 2 g | 8 g | 7 g | 308 IU | 30 mg | 233 mg | 0.03 mg | 0.04 mg | 0.04 mg | 36 μg
Blueberries | 145 g | 0 g | 1 g | 4 g | 14 g | 78 IU | 14 mg | 112 mg | 0.05 mg | 0.06 mg | 0.08 mg | 9 μg
Strawberries | 147 g | 0 g | 1 g | 3 g | 7 g | 18 IU | 86 mg | 225 mg | 0.04 mg | 0.03 mg | 0.07 mg | 35 μg

a Nutrient data were obtained from the USDA Nutrient Database for Standard Reference (www.nal.usda.gov/fnic/foodcomp/search/)

#### Antioxidants in Berries

Antioxidants have protective effects against free radicals, highly reactive substances that result from normal metabolism and from exposure to environmental factors like cigarette smoke and ultraviolet light. Free radicals cause cellular damage by attacking the body's cell membranes, proteins, and DNA. Berries, such as blueberries, blackberries, cranberries, black raspberries, raspberries, and strawberries, have higher total antioxidant capacity than other fruits or vegetables, according to the commonly used oxygen radical absorbance capacity (ORAC) and ferric-reducing ability of plasma (FRAP) assays.^164,^ ^166^–^168^ The ORAC assay is based on an antioxidant's ability to react with or neutralize free radicals generated in the assay systems. The FRAP assay measures the reduction of ferric iron (Fe^3+^, oxidized form) to ferrous iron (Fe^2+^, reduced form) in the presence of antioxidants.^167^

Flavonoids are members of the polyphenol family, important phytochemicals derived from plants and having a combination of anti-oxidative, anti-viral, and anti-carcinogenic properties (Figure 2). Although the predominant flavonoid depends on variety and species, flavonoids are found mostly in celery, cranberries, onions, kale, dark chocolate, broccoli, apples, cherries, berries, tea, red wine, purple grape juice, parsley, soybeans, tomatoes, eggplant, and thyme^.163^ Anthocyanins and/or proanthocyanidins (a class of flavonoid compounds) are the main antioxidants compounds found in berries, and they might have anti-inflammatory effects.

Figure 2. Polyphenol family structure

### Animal and In Vitro Studies: Mechanisms of Action

All studies related to mechanisms of action of berry constituents (or whole berries) have been performed in animal or in vitro models. Among 18 animal or in vitro studies (with 19 experiments) investigating berries and neurocognitive function or processes, four studies^169^–^172^ examined the effects of specific berry constituents on animal performance in neurocognitive testing or on their brain biochemistry. The remaining 14 studies (with 15 experiments)^173^–^186^ used berry extracts that supplemented normal diet or were added to in vitro media.

#### Effects of the Constituents in Berries

Study Descriptions. Four studies, two of high quality and two of moderate quality, were included in this section. ^169^–^172^ Of the four studies, only a limited number of the numerous constituents in berries have been examined. These include tannins, anthocyanin and phenolics, from various berries (Table 40). Each study examined the effects of different berry constituents.

Table 40 Effects of constituents in berries on animal's performance in neurocognitive testing or on their brain biochemistry

Study, Year | Model Age/Weight | | Duration | Intervention | | | N | Control | N | Neurocognitive Test | Group | Results | P | Biochemical Measures | Group | Results | P | Quality
Saija, 1990 | Rats | S-D 300–350 g | 3days | Bilberry anthocyanins^a^ | | 200 mg/kgi.p. | nd | Vehicle | nd | | | | | Brain uptake of T3 | | + | <.05^b^ | B
Wang, 1996 | Rat brain | PKC ^c^ | | Blueberry tannins^d^ | | | | (Other tannins) | | | | | | Brain PKC inhibition | | 0^e^ | NS btw tannins | A
| | | | Red currant tannins^f^ | | | | | | | | | | | | 0^e^
| | | | Gooseberry tannins^g^ | | | | | | | | | | | | 0^e^
Andres-Lacueva, 2005 | Rat, male | F344 19 mo | 7–10 wk | Blueberry extracts | | 2% of diet | 8/4^h^ | NIH-31 w/ 2% dried corn | 8/4 | MWM- time to reach platform | | 0 | | Anthocyanin profile distribution in brain regions (cerebellum, cortex, striatum; hippocampus) | | + | nd | A
| | | | | | | | | | MWM- time searching | | 0
Shukitt-Hale, 2005 | Rat, male | F344 19 mo | 13 16 wk | BB | An: 1.3 | Ph: 1.2 | nd | NIH-31 | nd | Rod Walk | All | 0 | | Dopamine release | BB | nd | | B
| | | | BC | An: 8.7 | Ph: 2.9 | nd | | | Wire Suspension | All | 0 | | | BC | + | .004
| | | | BS | An: 9.2 | Ph: 2.0 | nd | | | Plank Walk | All | 0 | | | BS | 0
| | | | CB | An: 3.3 | Ph: 3.6 | nd | | | Inclined Screen | BB | + | .04 | | CB | + | .007
| | | | | | | | | | | BC | 0 | | Hippocampal HSP70 | BB | + | .001
| | | | | | | | | | | BS | 0 | | | BC | 0
| | | | | | | | | | | CB | + | .001 | | BS | 0
| | | | | | | | | | Accelerating Rotarod | All | 0 | | | CB | ~+ | .06
| | | | | | | | | | Morris Water Maze | All | 0

An = anthocyanin (mg/g extracts), BB = blueberry extracts, BC = black currant extracts, BS = boysenberry extracts, btw = between, CB = cranberry extracts, F344 = Fischer 344, HSP70 = heat shock protein 70, i.p. = intra-peritoneal, N/A = not applicable, nd = no data or not done, NS = not statistically significant, Ph = total phenolics (mg/g extracts), PKC = protein kinase C, S-D = Sprague-Dawley, T3 = triiodothyronine, MWM = Morris Water Maze.

+Berry-fed animals performed better than non-berry-fed animals

0No difference in performance

-Berry-fed animals performed worse than non-berry-fed animals

a Extract containing up to15 anthocyanins.

b A significant increase in T3 transport into frontal cortex, temporoparietal cortex, occipital cortex, hippocampus, thalamus, hypothalamus and brain-stem, but no significant change in T3 transport into striatum, inferior colliculus, and cerebellum.

c Study measured the concentrations of 18 plant tannins required for 50% inhibition (IC50 values) of brain PKC.

d Containing 77% procyanidin and 23% prodelphinidin.

e Compared to non-berry tannins.

f Containing 78% procyanidin and 22% prodelphinidin.

g Containing 96% procyanidin and 4% prodelphinidin.

h 8 animals per group for neurocognitive test between 7 and 8 weeks after receiving the diets; brains from 4 animals per group were harvested for brain biochemical measures after 10 weeks of diets.

Overall Effects. Saija 1990 found that injecting 200 mg/kg bilberry anthocyanin extracts intraperitoneally in adult rats for 3 days significantly increased rats' brain uptake of triiodothyronine (T3).^169^ The findings generated the hypothesis that the berry anthocyanins might cross the BBB and block the 5′-deiodinase activity and, therefore, the intracerebral formation of T3 from T4, thereby simultaneously stimulating T3 transport into the brain.

Wang 1996 measured the concentrations of tannins from 18 plant sources that were required for 50 percent inhibition (IC_50_ values) of brain protein kinase C (PKC). Wang found that blueberry, red currant, and gooseberry tannins have similar IC_50_ values as other plant tannins. Additionally, the IC_50_ values of these three tannins were not significantly different from each other. No measurements were made regarding possible effects of PKC inhibition.^171^ PKC is known to be involved in eukaryote cell signal transduction.

Andres-Lacueva 2005 assessed whether anthocyanins might be found in brain areas associated with cognitive performance following blueberry supplementation in old rats, and the effects of the blueberry supplementation in rats' diet on the performance of Morris Water Maze. The rats' standard diet was augmented with either blueberry extracts or dried corn, which replaced 2 percent of the diet. They found that following 10 weeks of dietary supplementation with 2 percent of blueberry extracts, anthocyanins were found in the brains of all rats fed the blueberry diet, while no anthocyanins were detected in the brains of rats fed the corn diet. There was no difference in Morris Water Maze escape latency learning over days between blueberry- and corn-fed rats. However, among blueberry-fed rats, there was a significant negative correlation between day 4 re-learning (mean latency for trials 2–6) and number of total anthocyanins measured in the cortex (r=-0.78, P=0.02); i.e., as anthocyanin number increased, the latency to find the platform decreased. Also as anthocyanin number increased, there was a trend for the rat to spend more time searching in the location of the previous platform location on the probe trial (r=0.91, P=0.09).

Shukitt-Hale 2005 is the only study that compared the effects of specific berry constituents on neurocognitive outcomes. They examined aged rats' performance in neurocognitive testing, along with possible mechanisms of action regarding brain biochemical changes. The rats' standard diet was augmented with each of four berry extracts, which replaced 2 percent of the diet. The total phenolics in these four berry extracts were similar, while black currant or boysenberry extracts had higher amount of anthocyanin than blueberry or cranberry extracts. They tested whether the loss of the ability of cells to increase the biomarker heat shock protein (HSP70), as a means to respond to insults such as ischemia, inflammatory agents and reactive oxygen species, may contribute to the age-related declines in both neuronal and behavioral functioning. In addition, striatal dopamine release was assessed because it is believed to be a sensitive marker for assessing striatal muscarinic sensitivity in aging.

Blueberry and cranberry extracts, but not black currant and boysenberry extracts, had a significant beneficial effect on performance by the rats on the inclined screen test, one of five psychomotor functions tested. The cranberry extract group (that had improved function) and the black currant extract group (that did not have improved function) had significantly increased striatal dopamine release compared to the control and boysenberry extract groups; the blueberry extract group was not examined for dopamine release.

HSP70 responsiveness in the blueberry extract group was significantly higher than the control group and the cranberry extract group showed a trend toward higher HSP70 responsiveness than the control group, while the black currant and boysenberry extract groups did not show such responsiveness. Furthermore, rats' neurocognitive performance, as measured by latency to fall from the inclined screen, was positively related to the percent change in HSP70 (r=0.39, P=0.05).

The inclined screen, dopamine release and HSP70 results all suggested that there is a range of effectiveness associated with the different berry extracts. However, it does not appear that the anthocyanin component is solely responsible for these improvements, as the black currant and boysenberry extracts are higher in anthocyanin level, but not as effective in improving motor performance. Of note, there was no significant effect on rats' performance in the Morris Water Maze among the four berry extract groups when compared to control. This test is among the more standardized and validated tests of neurocognitive and behavioral function in rodents.^187^

Summary. Of the four included studies, only a limited number of the numerous constituents in berries have been examined. Each study examined the effects of different berry constituents. One study showed that injecting 200 mg per kg bilberry anthocyanin extracts intraperitoneally in adult rats for 3 days significantly increased rat's brain uptake of T3. Another study measured the IC_50_ of brain PKC for 18 plant tannins in an in vitro study. Blueberry, red currant, and gooseberry tannins have similar IC_50_ values as other plant tannins. Additionally, the IC_50_ values of these three tannins were not significantly different from each other. However, the biological significance of this in vitro study in live animals is unknown. Only the most recent studies evaluated the effects of specific berry constituents on neurocognitive outcomes. Two studies examined aged rats' performance in neurocognitive testing: both found no difference in the learning performances; one found improvements in motor performances. Of these, one study also demonstrated that the anthocyanins in blueberry extracts were able to cross the BBB and the number of the total anthocyanins measured in the brain is associated with rats' learning performance. Another study examined the possible mechanisms of action regarding brain biochemical changes to rats' performance in neurocognitive testing. The results suggested that there is a range of effectiveness associated with the different berry extracts as shown in the results from rats' performance in the inclined screen test, dopamine release and heat shock protein. However, it does not appear that the anthocyanin component of the berry extracts is solely responsible for these improvements, as the black currant and boysenberry extracts are higher in anthocyanin level, but not as effective in improving motor performance.

#### Effects of Berry Extract Supplementation

Berry extracts were used to supplement animals' diet or added to in vitro study media in 14 studies with 15 experiments that examined animal's performance in neurocognitive testing or brain biochemistry or histology.^173^–^186^ Of these, two studies used specific animal or in vitro models of AD. The remaining 13 studies used adult or aged rat models. All of these studies (including the rat neurocognitive function study described above) are from the same group of investigators.

Study Descriptions. Only limited types of berry extracts were examined across the 14 studies with 15 experiments (Table 41). Blueberry extracts were used in 11 studies, of which only one study specified the species of blueberries (i.e., “wild” vs. “tif-blue” blueberries, a variety of rabbiteye blueberry).^186^ Strawberry extracts were used in 11 studies, none of which reported the species. Seven of these studies used both blueberry and strawberry extracts, including one study that used five different berry extracts, including blueberry, strawberry, black currant, boysenberry, and cranberry extracts.^181^ All berry extracts were freeze-dried and aqueous extracted, prepared by homogenizing, centrifuging, and then freeze drying. All 13 studies that used adult or aged rat models were based on a single central hypothesis, namely that the increase in dietary antioxidant levels (by supplementation with berry extracts) might decrease the aging-induced oxidative stress (and/or various physiological changes due to the increased oxidative stress) thus reversing the age-related neurodegenerative deficits. However, the studies did not elaborate on which “antioxidants” in these berry extracts might be responsible for the effects. With a similar central hypothesis, the two studies of animal or in vitro models of AD further examined the effects of berry extracts on fibrillar amyloid β deposits in mice's brain and on Ca^2+^ recovery following amyloid β treatment in vitro.^180,^ ^181^ Most studies are of high quality. Studies that were downgraded to moderate or poor quality were due to poor reporting, no repeated measures, or lack of neurocognitive function measures.

Table 41 Effects of berry extracts on animal performance on neurocognitive testing or brain biochemistry or histology

Study, Year | Model Age/Weight | | Duration (mo) | Intervention | | N | Control | N | Neurocognitive Test | Group | Results | P | Biochemical / Histology Measure | | Results | P | Quality
Normal aging model
Joseph, 1998A | Rats | F344, 6 8mo | 2 | Blueberry extracts | 10 g/kg | nd | AIN-93 | nd | | | | | Dopamine release^e^ | B | + | nd | C
| | | | | | | | | | | | | | S | + | nd
| | | | Strawberry extracts | 9.4 g/kg | nd | | | | | | | Cerebellar β adrenergic receptor function | B | + | <.01
| | | | | | | | | | | | | | S | + | <.01
Joseph, 1998B | Rats, male | Fischer, | 8 | Strawberry extracts | 9.5 g/kg | 8^a^ | Modified AIN 93 | 8^a^ | MWM: Latency | | + | <.05 | Dopamine release (striatal) | | + | <.03 | A
| | 6 mo | | | | | | | MWM: Distance | | + | <.01 | Ca^2+^ recovery after H_2_O_2_ exposure (synaptosomes) | | + | <.02
| | | | | | | | | MWM: Memory | | 0 | | Oxidative stress (cerebellar) | | + | <.0001
| | | | | | | | | | | | | GTPase activity (striatal) | | + | <.0001
Bickford, 1999 | Rats | F344, 6mo | 2 | Blueberry extracts | 10 g/kg | nd | AIN-93 | | Rod walking^e^ | B | + | nd | Cerebellar ISO potentiation of GABAergic inhibition^e^ | B | + | nd | C
| | | | Strawberry extracts | 9.4 g/kg | nd | | | | S | + | nd | | S | + | nd
Bickford, 1999 | Rats | F344, 6mo | 9 | Strawberry extracts | 9.4 g/kg | nd | AIN-93 | | | | | | Cerebellar β adrenergic receptor function | | + | <.01 | C
Joseph, 1999 | Rats | F344, 19mo | 2 | Blueberry extracts | 10 g/kg | 10 | Modified AIN 93 | 10 | Rod walking time | B | + | <.05 | Dopamine release (striatal) | B | + | <.0001 | A
| | | | | | | | | | S | + | <.05 | | S | + | <.0001
| | | | Strawberry extracts | 9.4 g/kg | 10 | | | Rod walking (latency to fall) | B | + | <.01 | GTPase activity (striatal) | B | + | <.001
| | | | | | | | | | S | + | <.01 | | S | 0
| | | | | | | | | Wire suspension | B | 0 | | Ca recovery after H_2_O_2_ exposure (synaptosomes) | B | + | <.05
| | | | | | | | | | S | 0 | | | S | 0
| | | | | | | | | Plank walking | B | 0 | | Oxidative stress (striatal) | B | + | <.005
| | | | | | | | | | S | 0 | | | S | + | <.002
| | | | | | | | | Inclined screen | B | 0
| | | | | | | | | | S | 0
| | | | | | | | | Accelerating rotarod time | B | + | <.05
| | | | | | | | | | S | + | <.05
| | | | | | | | | Accelerating rotarod (latency to fall) | B | ~+ | 0.06
| | | | | | | | | | S | 0
| | | | | | | | | MWM: Memory (learning trial 1→2) | B | + | <.01
| | | | | | | | | | S | + | <.05
Shukitt-Hale, 1999 | Rats | C57BL.6NIA, 18 mo | 6 | Strawberry extracts | 1% of diet | 10 | Modified AIN76 | 8 | Rod walking | | 0 | | | | | | A
| | | | | | | | | Wire suspension/wire hanging | | 0
| | | | | | | | | Plank walking | | 0
| | | | | | | | | Inclined screen | | 0
Bickford, 2000 | Rats, male | F344, 18mo | 2 | Blueberry extracts | 18.6 g/kg | 8 | Modified AIN 93 | 14 | Rod walking asymptote (time improvement) | B | 0 | | Cerebellar ISO potentiation of GABAergic inhibition | B | + | <.001 | A
| | | | | | | | | | S | 0 | | | S | + | <.05
| | | | Strawberry extracts | 14.8 g/kg | 8 | | | Rod walking slope (rate of learning) | B | 0
| | | | | | | | | | S | 0
Martin, 2000 | Rats, male | F344, 15mo | 8 | Strawberry extracts | 9.5 g/kg | 20 | Modified AIN 93 | 20 | | | | | Dopamine release (striatal) | | + | <.05 | B
Youdim, 2000 | Rats, male | F344, 17mo | 2 | Blueberry extracts, “wild” | 2% of diet | 14 | Modified NIH-31^b^ | 12 | Accelerating rotarod (latency to fall) | Bw | + | <.05 | Dopamine release (striatal) | Bw | + | <.05 | A
| | | | | | | | | | Bt | 0 | | | Bt | + | <.05
| | | | | | | | | Inclined screen (latency to fall) | Bw | 0
| | | | | | | | | | Bt | ~+ | 0.06
| | | | Blueberry extracts, “tif-blue” | 2% of diet | 13 | | | Plank walking (latency to fall) | Bw | + | <.05
| | | | | | | | | | Bt | + | <.05
| | | | | | | | | MWM (latency to find platform) - trial 1 | Bw | 0
| | | | | | | | | | Bt | + | <.05
| | | | | | | | | MWM (latency to find platform) - trial 2 | Bw | 0
| | | | | | | | | | Bt | 0
Casadesus, 2004 | Rats, male | F344, 19mo | 2 | Blueberry extracts | 2% of diet | 5 | NIH-31 | 5 | Reference memory errors | Day 1–3 | 0 | | Proliferation of precursor cells in the dentate gyrus | | + | <.05 | A
| | | | | | | | | | Day 4 | + | <.05
| | | | | | | | | | Day 5 | 0
| | | | | | | | | Working memory errors | Day 1–3 | 0 | | Hippocampus growth factor-1 (IGF-1) | | + | <.001
| | | | | | | | | | Day 4 | + | <.06
| | | | | | | | | | Day 5 | 0
| | | | | | | | | Total memory errors | Day 1–3 | 0 | | Hippocampus growth factor-1R (IGF-1R) | | + | <.005
| | | | | | | | | | Day 4 | + | <.05
| | | | | | | | | | Day 5 | 0
| | | | | | | | | | | | | Extracellular-signal-regulated-kinase (ERK) activation | | + | <.01
Goyarzu, 2004 | Rats, male | F344, 15or 4 mo | 4 | Blueberry extracts | 2% of diet | 12 | NIH-31, 15mo | 12 | Object recognition,1 hr delay | Aged Ctrl | + | <.01 | Brain NF-κB levels^g^ | Aged Ctrl | +^h^ | <.03 | A
| | | | | | | NIH-31, 4mo | 12 | | Young Ctrl | 0 | | | Young Ctrl | 0^i^
Rabin, 2005A | Rat, male | S-D | 2^j^ | Blueberry extracts | 2% of diet | 4 | Modified NIH-31 | 8 | Operant task / bar pressing, with fixed ratio reinforcement | 6 mo pFe | 0 | | | | | | A
| | 175–200 g | | | | | | | | 12 mo pFe | 0
| | | | Strawberry extracts | 2% of diet | 4 | | | | 6 mo pFe | 0
| | | | | | | | | | 12 mo pFe | 0
| | | | Blueberry extracts + 1.5 Gy ^56^Fe | 2% of diet | 8 | Modified NIH-31 + ^56^Fe | 8 | | 6 mo pFe | 0
| | | | | | | | | | 12 mo pFe | 0
| | | | Strawberry extracts + 1.5 Gy ^56^Fe | 2% of diet | 8 | | | | 6 mo pFe | 0
| | | | | | | | | | 12 mo pFe | + | <.05
Rabin, 2005B | Rat, male | S-D | 2^j^ | Blueberry extracts | 2% of diet | 4 | Modified NIH-31 | 8 | Operant task / bar pressing, with fixed ratio reinforcement | Age 9, 12 mo | 0 | | | | | | A
| | 175–200 g | | | | | | | | Age ?,? | 0
| | | | Strawberry extracts | 2% of diet | 4 | | | | Age 9, 12 mo | 0
| | | | | | | | | | Age ?,? | 0
| | | | Blueberry extracts + 2.0 Gy ^56^Fe | 2% of diet | 8 | Modified NIH-31 + ^56^Fe | 8 | | Age 9, 12 mo | 0
| | | | | | | | | | Age ?,? | 0
| | | | Strawberry extracts + 2.0 Gy ^56^Fe | 2% of diet | 8 | | | | Age 9, 12 mo | + | <.05
| | | | | | | | | | Age ?,? | 0
Alzheimer's disease model
Joseph, 2003 | Mice | Transgenic^f^, 4 mo | 12 | Blueberry extracts | 2% of diet | 3 | Modified NIH-31 | 3 | Y maze performance | Tg | + | <.05 | Fibrillar Amyloid β deposits | Tg | 0 | | A
| | | | | | | | | | W | 0 | | | W | nd
| | | | | | | | | | | | | N-Sase activity (striatal, hippocampal & cortex)^c^ | Tg | + | <.01
| | | | | | | | | | | | | | W | + | <.01
| Mice | Wild type, 4 mo | | | | 3 | | 3 | | | | | Low Km GTPase activity (striatal)^c^ | Tg | + | <.05
| | | | | | | | | | | | | | W | 0
| | | | | | | | | | | | | ERK activity (hippocampal)^d^ | Tg | + | <.001
| | | | | | | | | | | | | | W | 0
| | | | | | | | | | | | | Phospho PKCα (hippocampal)^c^ | Tg | + | <.05
| | | | | | | | | | | | | | W | 0
| | | | | | | | | | | | | PKCγ (striatal, hippocampal & cortex)^c,e^ | Tg | 0
| | | | | | | | | | | | | | W | 0
Joseph, 2004 | COS-7 cells (ATCC) transfected with rat muscarinic receptor subtype 1 or 3 DNA | | | Blueberry extracts | 2 mg/ml | | | | | | | | Ca^2+^ Recovery following 0 or 1 mM dopamine Rx | B | + | <.001 | B
| | | | Blackcurrant extracts | 2 mg/ml | | | | | | | | | Bc | + | <.05
| | | | Boysenberry extracts | 2 mg/ml | No fruit extract pre-Rx | | | | | | | | By | + | <.001
| | | | Strawberry extracts | 0.5 mg/ml | | | | | | | | | S | + | <.01
| | | | Cranberry extracts | 1.0 mg/ml | | | | | | | | | C | + | <.05
| | | | | | | | | | | | | Ca^2+^ Recovery following 0 or 100 μM Aβ (25–35, 100 μM) Rx | B | + | <.05
| | | | | | | | | | | | | | Bc | + | <.05
| | | | | | | | | | | | | | By | + | <.05
| | | | | | | | | | | | | | S | 0
| | | | | | | | | | | | | | C | + | <.05

Aged Ctrl=when compared to the aged controls; Aβ= Rx=treatment; B=Blueberry extracts; Bc=Blackcurrant extracts; Bt=Blueberry extracts, tif-blue; Bw=Blueberry extracts, wild; By=Boysenberry extracts; C=Cranberry extracts; F344=Fischer 344; MWM=Morris water maze; nd=no data or not done; NF-κB=nuclear factor-kappa B; N-Sase=neutral sphingomyelin-specific phospholipase; pFe=after irradiation with Fe; PKC=protein kinase C; S=Strawberry extracts; S-D=Sprague-Dawley; Young Ctrl=when compared to the young controls.

+ Berry-fed animals performed better than non-berry-fed animals

0 No difference in performance

- Berry-fed animals performed worse than non-berry-fed animals

a The number of animals per group was assumed from the total number of animals reported in the article.

b Information was inferred from subsequent publications. Control diet specification was, however, described in detailed as table format in the paper.

c 3 regions of brain were examined in this study, including striatal, hippocampus, and cortex. There was no significant effect was found in both groups if the brain region is not indicated in the parenthesis.

d Striatal and cortex regions were not examined for ERK activities

e Data not shown

f Transgenic for amyloid precursor protein (APP) and presenilin-1 (PS1) mutations; prone to fibrillar amyloid beta deposits in cerebral cortex and hippocampus and changes in cognitive behavior in later life

g Brain regions examined including frontal cortex, hippocampus, basal forebrain, stratum and cerebellum.

h In all regions except the basal forebrain, the difference was significant.

i In all regions except for the cerebellum, there was no significant difference between the aged rats fed blueberry-enrich diet and the young controls. In the cerebellum, the aged rats maintained on the blueberry-enriched diet had significantly higher NF-κB levels than young control. Notably, aged rats maintained on the control diet had significantly higher NF-κB levels than young rats maintained on the control diet in all regions except the striatum.

j Diet for 2 months; follow-up for 18 months.

##### Overall Effect

Blueberry extract supplementation. The effects of blueberry supplementation on animal's performance in neurocognitive testing or brain biochemistry or histology in adult or aged rat models are summarized in Figure 3. In these nine studies, blueberry extract supplementation showed positive or protective effects on all biochemical markers and histology findings examined in rats' brain, although only some of the neurocognitive tests and psychomotor functions were significantly improved in blueberry-extract-fed rats. Only one study correlated the biochemical markers changes in rats' brain with rats' performances in cognitive function tests.^175^ Nineteen-month-old male F344 rats were fed either the control diet or the blueberry-extract diet for 8 weeks before they were tested for Radial Arm Water Maze (RAWM) performances. The blueberry-extract diet equaled 2 percent of the control diet supplemented with blueberry extracts, which was approximately equivalent to the consumption of 4 g of blueberry extract per day. RAWM performance was tested for five consecutive days. Repeated measure analysis across days revealed a significant day effect for latency (P<0.0001), suggesting that rats in both groups could successfully learn the task on days 1 to 3. The lack of interaction between groups suggested that the rate of learning on days 1 to 3 did not differ across groups. On day 4, compared to animals fed the control diet, blueberry-extract-fed rats had significantly fewer reference memory errors (P<0.05) and total memory errors (P<0.05), and also showed a trend towards fewer working memory errors (P<0.06). However, there was no significant difference in RAWM performances seen between the two groups on day 5. It was also found that the blueberry extract supplementation significantly increased hippocampus insulin growth factor-1 (IGF-1), IGF-1R, and extracellular-signal-regulated-kinase (ERK) activation. These changes of brain biomarkers were significantly associated with the decreases in total memory errors and reference memory errors but not working memory errors on day 4. In addition, blueberry extract supplementation significantly increased proliferation of precursor cells in the dentate gyrus (or neurogenesis) and the neurogenesis was significantly associated with the improvements in RAWM tests. Finally, in order to see if neurogenesis, growth factors, and ERK, in combination or synergistically, were associated with the improvements in RAWM tests in aged blueberry-extract-supplemented rats, the associations between these brain biomarkers were examined. A statistically significant positive correlation between ERK activation and IGF-1 and IGF-1R levels was found (r=0.75, P<0.05), while the increased IGF-1 and IGF-1R levels, and ERK activation were not associated with neurogenesis.

Figure 3. Summary of the effects of blueberry extract supplementation on animal's performance in neurocognitive testing or brain biochemistry or histology in adult or aged rat models

Strawberry extract supplementation. The effects of strawberry supplementation on animal's performance in neurocognitive testing or brain biochemistry or histology in adult or aged rat models are summarized in Figure 4. Nine of 10 studies showed positive or protective effects of strawberry-extract supplementation on all of the biochemical markers examined in rats' brain, although only some of the neurocognitive tests and psychomotor functions were significantly improved in strawberry-extract-fed rats. No study correlated the biochemical markers changes in rats' brain with rats' performances in neurocognitive function tests.

Figure 4. Summary of the effects of strawberry extract supplementation on animal's performance in neurocognitive testing or brain biochemistry or histology in adult or aged rat models

Alzheimer's disease models. One animal study^180^ and in vitro study^181^ used models of AD to examine the effects of berry extracts.

In the animal study, mice transgenic for amyloid precursor protein (APP) and presenilin-1 (PS1) mutations were used to model human AD.^180^ These mice are prone to fibrillar amyloid β deposits in cerebral cortex and hippocampus early in the life-span with later changes in cognitive behavior. Four-month-old transgenic and wild type mice were fed either the control diet or the blueberry-extract diet for 12 weeks before they were tested for Y maze performances. The blueberry-extract diet was 2 percent of the control diet supplemented with blueberry extracts, which was approximately equivalent to the consumption of 4 g of blueberry extract per day. Blueberry extract supplementation had a beneficial effect on Y-maze performance in transgenic mice but not in wild type mice. In the transgenic mice, there was no significant change in brain amyloid β deposits or calcium-dependent phospho-protein kinase Cα (PKCα), while a significant increase in brain neutral sphingomyelin-specific phospholipase C (N-Sase), low Km guanosine triphosphase (GTPase), ERK, and protein kinase Cγ (PKCγ) activities was found. Furthermore, the correlation between these brain biomarkers and the Y maze performances by the mice was examined. A positive correlation between GTPase activity and Y-maze alternation was found in the striatum but not in the hippocampus or cortex. A negative correlation between N-Sase activity and Y-maze alternation was found in the striatum but not in the hippocampus or cortex. The correlation between all other brain biomarkers and Y-maze alternation did not reach statistical significance.

In the in vitro study, COS-7 cells (ATCC) transfected with rat muscarinic receptor subtype 1 or 3 DNA (M1AchR) were used.^181^ Five different berry extracts (2 mg per mL blueberry, 2 mg per mL black currant, 2 mg per mL boysenberry, 0.5 mg per mL strawberry, or 1 mg per mL cranberry extracts) were dissolved in growth media and M1AchR-transfected COS-7 cells were subsequently incubated with the treated growth medium. Following these incubations the cells were washed with extract-free growth medium prior to testing. Ca^2+^ Recovery following 0 or 1 mM dopamine or 0 or 100 μM amyloid β treatment was tested. Recovery was determined by assessing the time (within 300 sec) for the Ca^2+^ level to return to 20 percent of the increase following depolarization in the cells that responded. In the absence of pre-treatment (control condition) there were significant effects of both dopamine and amyloid β on recovery of the M1-transfected cells (e.g., control vs. dopamine- or amyloid β-treated cells with no extract pre-treatment, P<0.001) and all berry extract pre-treatments did not show any significant effect on Ca^2+^ recovery. However, all five berry extract pre-treatments significantly reduced the deleterious effects of dopamine, and blueberry, black currant, boysenberry and cranberry but not strawberry, extract pre-treatments significantly reduced the putative toxic effects of amyloid β.

Summary. Only strawberry and blueberry extracts were used to examine the effects of extract supplementation on animal performance in neurocognitive testing or brain biochemistry or histology using a normal-aging rat model. The mechanism of actions tested were similar for both berry extracts although only one study, using blueberry extract, examined the direct relationship between the changes in brain biomarkers and the performance in neurocognitive function tests. Blueberry and strawberry extract supplementation showed positive or protective effects on almost all biochemical markers and histology findings examined in rats' brain, although only some of the neurocognitive tests and psychomotor functions were significantly improved in these berry-extract-fed rats.

Only two studies used models of AD to examine the effects of various berry extracts. The results suggested that it may be possible to reduce both the deleterious effects of dopamine and the putative toxic effects of amyloid β via various berry extracts as shown in the in vitro study. Results from the animal study that used mice transgenic for APP and PS1 mutations to model human AD showed that the blueberry extract supplementation seemed to have prevented the deficits in Y-maze performance seen in the transgenic animals fed the control diets, although it did not affect amyloid β deposits.

### Human Studies

Only one study examined the association between consumption of berries and age-related neurodegenerative disorders. In the late 1980s, Golbe et al. (1988) conducted a case-control study to examine the association between fruit and vegetable consumption in early life and the risk of PD among a group of non-vegetarian PD patients and their same-sex siblings The mean age of the participants at the time of survey was 62 years old.^188^ Seventeen food items including fruit, vegetables, nuts, and salad oil or dressing were examined. Patients and same-sex siblings, in separate interviews, were each asked whether they or their spouse were more likely to eat each item between the time of marriage and age 40 years. Patients and siblings were first categorized by whether they consumed more, less, or the same amounts of different foods as their own spouses. Patient and sibling pairs (including spouses) were then categorized as concordant or discordant in their dietary habits (using an unverified, arbitrary decision process). Using discordant patient-sibling pairs, the odds ratio of PD was based on the patients who ate more of a food than their siblings compared to those who ate less. It was found that the preference to consume blueberries or strawberries was not statistically significantly associated with presence of PD. This study was deemed to be of poor quality due to measurement and recall biases, in addition to the unusual definitions for the consumption levels of fruit and vegetables, and the unverified categorization technique and statistical analysis.

We found no human interventional studies or clinical trials that met eligibility criteria and no correlational or observational study that evaluated AD.

#### Berry Adverse Events

The single human study of berry consumption was retrospective, therefore no study provided data regarding adverse events from berries in the setting of neurocognitive disorders. An electronic search (of MEDLINE^®^ and CAB Abstracts™) for review and primary articles reporting on adverse events related to berries or berry constituents (not including allergic reactions or occupational exposures) identified two primary reports and a systematic review. This search captured only articles that were tagged for adverse events.

Canter and Ernst performed a systematic review of trials of bilberry-extracted anthocyanins for night vision.^189^ They reported no adverse events in any of 12 eligible studies; although they did not clarify if adverse events were actually reported in these studies. They also reported in a post-marketing study of 2,295 participants, that 94 complained of side effects that were mainly gastrointestinal, or related to the skin or nervous system.^189,^ ^190^

An RCT of blackcurrant seed oil treatment for rheumatoid arthritis reported no dropouts due to adverse reactions.^191^ One abstract of a case report described a man in his 70s, treated with digoxin, phenytoin, and warfarin, who had poor appetite and drank only cranberry juice post-chest infection.^192^ After 6 weeks, the patient's international normalized ratio (INR) was greater than 50. The author noted that the Committee on Safety of Medicines has received seven other reports of possible interaction between warfarin and cranberry juice leading to changes in INR or bleeding.