# Introduction

The report on B Vitamins and Berries and Age-Related Neurodegenerative Disorders consists of 2 separate, but related, systematic reviews. Although sharing the same outcomes of interest, research on the effects of B vitamins and on the effects of berries do not overlap. However, given the shared outcomes of interest and the small amount of literature on berries research, this report covers both topics. The report is structured such that each chapter includes separate sections for information regarding both topics, for the B vitamin topic, and for the berries topic. In particular, the Results chapter is divided into 2 sections, one each for the B vitamin topic and the berries topic.

We begin with a general overview of age-related neurodegenerative disorders, followed by information on B vitamins and their proposed mechanisms of actions on age-related neurodegenerative disorders, and subsequently a brief introduction to berries and their proposed mechanisms of action. A detailed discussion about berry constituents is reserved for the Results chapter in response to the first berry Key Question.

## Overview of Age-Related Neurodegenerative Disorders

Disorders of the nervous system account for more long-term care, chronic suffering, and lost quality of life than all other disorders combined.^1^ Age-related neurodegenerative disorders are chronic and progressive conditions that result from loss of the maintenance of neurons involved in cognitive, emotional, motor and sensory functions.^2^ Different neurological disorders are associated with different patterns of cell loss and different intra- or extracellular deficiencies (such as changes in the intracellular signal transduction pathways and intercellular signal molecules) or deposits in the brain. The two most common age-related neurodegenerative disorders are Alzheimer's and Parkinson's diseases.

Alzheimer's disease (AD) affects over 4 million people in the United States.^2^ It is the cause of about two-thirds of all cases of dementia.^3^ The prevalence of AD rises exponentially with age among the elderly such that up to half of 95 year olds are affected.^4^ AD is a progressive neurological disease that results in the irreversible loss of brain neurons. It results in progressive impairment in memory, judgment, decision making, orientation to physical surroundings and language. Definitive diagnosis can be made only at autopsy, where the pathological hallmarks are neuronal loss, amyloid β-peptide plaques, and neurofibrillary tangles (or tau proteins). Human, animal model, and in vitro studies of AD generally focus on cognitive and language function or changes related to the pathological hallmarks.

The major dementia syndromes include AD, vascular disease, Lewy body dementia, Parkinson's disease with dementia, frontotemporal dementias, and reversible dementias. The most common form of dementia among elderly is AD followed by the vascular dementia. AD has one or more of the following clinical features: a decrease in the level of cognition, behavioral disturbance, and interference to activities of daily living and independence. The most frequent clinical symptom is impairment in short and long-term memory. AD is synonymously known as dementia of Alzheimer disease, presenile and senile dementia, senile dementia of Alzheimer type, etc. AD is also categorized as type 1, type 2, type 3, and type 4 based on the age of onset, familial inheritance, genetic mutation, severity of disease and the rate progression.

The National Institute of Neurological and Communicative Disorders and Stroke and the Alzheimer's Disease and Related Disorders Association (NINCDS-ADRDA) includes criteria for diagnosis of AD that has an 80% positive predictive value.^5^ The Diagnostic and Statistical Manual of Mental Disorders - Fourth Edition (DSM-IV) also includes criteria for diagnosis of AD. The diagnosis of AD in a clinical setting involves careful history preferably from the caretaker or family of the patient, assessment of cognitive function, physical and neurological examination, and laboratory and imaging work-up of the patient. The most frequently used test to assess neurocognitive function is the Mini-Mental Examination (MMSE). Extensive evaluation of the multiple domains of the cognitive function can also be done using a battery of neuropsychological tests such as Dementia Rating Scale (DRS), the Wechsler Adult Intelligence Scale-Revised (WAIS-R), among others.

Parkinson's disease (PD) affects over 1 million people in North America,^6^ making it the second most common neurodegenerative disease.^3^ The prevalence of PD also rises with age, but at a much lower rate than AD; approximately 0.5 to 1 percent of 65 to 69 year olds are affected, rising to 1 to 3 percent among those 80 years and older.^7^ PD is characterized by resting tremor, bradykinesia (a decrease in spontaneity and movement), rigidity, and postural instability. Brain pathology is seen due to the loss of neurons in the substantia nigra in association with proteinaceous deposits known as Lewy bodies. Human, animal model, and in vitro studies of PD generally focus on related motor and neurological function or changes related to the pathological hallmarks.

A large number of other conditions result from progressive loss of neurons or neuronal function in various parts of the brain or due to numerous factors.^8^ These include mild “benign” motor and cognitive changes common among aging individuals and hundreds of rarely studied specific syndromes with heterogeneous clinical and pathological expressions.

Based on a recent review article, pharmacotherapy of AD and other dementias can only provide modest cognitive or disease-modifying benefits.^9^ However, even modest benefits may have significant effects on quality of life, caregiver burden, and societal economic costs. The principle recommended initial treatment for patients with AD is a cholinesterase inhibitor, regardless of severity illness. Other interventions are commonly tried, although none is recommended, primarily due to lack of evidence of a benefit. These include, among other treatments, hormone replacement therapy, anti-inflammatory treatments, gingko biloba, and various vitamin supplementations.

Basic science research has established the important role of genetics in both AD and PD. For AD, hypotheses have been proposed that mutations in precursor proteins and genes are associated with increased cellular production of products that are toxic to neurons. The first gene linked to familial AD is located on chromosome 21 and encodes the β-amyloid precursor protein (APP), the source of the 40 to 42 amino acid amyloid β-peptide that forms insoluble amyloid plaques in the brain of all AD patients. Two other genes linked to early-onset familial AD are those encoding presenilin-1 (PS1, on chromosome 14) and presenilin-2 (PS2, on chromosome 1).^10^ For PD, the alpha-synuclein gene (SNCA) has been implicated in autosomal dominant forms of the disease.^11^ There is a dosage effect according to the number of supernumerary copies of this gene (the number of gene duplications exceeding normal) in familial PD.^12^ Other factors that have been implicated in neuronal degeneration are mitochondrial dysfunction, oxidative stress, deficient neurotrophic support, and immune mechanisms.^6^

Although the mechanisms responsible for the neuronal degeneration seen during both normal aging and neurodegenerative disease states are not fully understood, the degeneration is thought to be caused by increased vulnerability to metabolic and extra-metabolic sources of free radicals in aging brains.^13^–^17^ An example of the possible role of oxidative stress in dementia is suggested by a recent study that found an increased plasma homocysteine level to be an independent risk factor for the development of dementia and AD in 1,092 participants (mean age, 77 years) from the Framingham cohort with a median follow-up of 8 years.^18^ With the variety of different possible pathogenic mechanisms in neuronal damage, development of therapies for these age-related neurodegenerative diseases will depend on further advances in our basic understanding of the underlying disease mechanisms. Such knowledge can potentially help in identifying high-risk individuals and lead to the development of therapies capable of halting the progression of the disorders before irreversible damage occurs.

## Proposed Mechanisms of the Effect of B Vitamins on Age-Related Neurodegenerative Disorders

Here and throughout the report, we focus of the specific B vitamins B1 (thiamine), B2 (riboflavin), B6 (primarily pyridoxine), B12 (cobalamin), and folate (folic acid, tetrahydrofolate, etc.). Thiamine and riboflavin exist in a variety of food sources, including enriched and whole-grain cereals, organ meats, milk, and various vegetables. A balanced diet is generally sufficient for adequate intake of these vitamins. Dietary vitamin B6 and B12 generally come from animal protein foods (including meat, poultry, seafood, and eggs) and enriched cereals, and the major food sources of folate include green vegetables, citrus fruits, various whole grains, and, recently folate-enriched flour.

Thiamine and riboflavin, along with niacin, function in various biochemical pathways in the metabolism of glucose, amino acids, and fatty acids.^19^ Thiamine deficiency, particularly associated with alcohol abuse, can result in Wernicke-Korsakoff syndrome, a distinct condition including dementia and psychosis resulting from lesions and thinning in multiple areas of the brain. There is increasing research in high-dose thiamine or riboflavin treatments in patients with AD and PD, even though the underlying mechanisms of action are unknown.^20^ A recent Cochrane systematic review of the efficacy of thiamine for people with AD was inconclusive due to the small number of randomized controlled trials and poor reporting of results in the included trials.^21^ The most common clinical manifestations reported in humans during vitamin B6 deficiency have been central nervous system changes and abnormal electroencephalography (EEG). Studies have showed that only 2 to 4 weeks of B6-depletion diet could result in abnormal EEG tracing in healthy young adults.^22,^ ^23^

The coenzymes of vitamin B12, folate, and vitamin B6 (methylcobalamine, methyl tetrahydrofolate and pyridoxal-5′-phosphate, respectively), along with choline, interact to control serum homocysteine levels.^19^ Increased levels of homocysteine, a metabolite of the amino acid methionine, as well as decreased folate and vitamin B12 levels have been associated with normal aging. Correlations between high serum concentrations of homocysteine (in conjunction with low folate, vitamin B6 and vitamin B12) and decreased performance on cognitive tests have been reported.^24,^ ^25^

Older adults are at risk of vitamin B12 deficiency because its absorption may decline with aging. Vitamin B12 is necessary for folate metabolism. Methionine synthase, a vitamin B12-dependent enzyme, facilitates the conversion of 5-methyltetahydrofolate to tetrahydrofolate by converting homocysteine to methionine. Derivatives of tetrahydrofolate are important for nucleotide biosynthesis. When deficiency of vitamin B12, dietary folate would stay methyltetrahydrofolate form in the body. The “methyltetrahydrofolate trap” phenomenon breaks the cycle of folate metabolism Folate acts as a cofactor in many biochemical reactions by donating and accepting one-carbon units.^11^ It is essential in nucleic acid synthesis and methylation reactions in the central nervous system. Animal and cell culture models of neurodegenerative disorders have shown that low-folate/high-homocysteine diets or folate deficiency may render neurons vulnerable to dysfunction and death. Specifically, dietary folate deficiency and elevated homocysteine levels were showed to promote accumulation of DNA damage and sensitizes neurons to amyloid β-peptide toxicity in experimental models of AD, and to endanger dopaminergic neurons in experimental models of PD.^26,^ ^27^ Also important to the evaluation of folate supplementation to prevent or treat neurodegenerative disorders is that excess folate intake can mask a vitamin B12 deficiency.^19^

Recommended Daily Allowances (RDA), Upper Limits (UL), and selected food sources of the B vitamins, as compiled by the Institute of Medicine (IOM) are presented in Table 1.

Table 1 Institute of Medicine Dietary Reference Intakes of B vitamins, functions, and sources

Nutrient | Function | Life Stage Group | RDA | UL^a^ | Selected Food Sources
Thiamine | Coenzyme in the metabolism of carbohydrates and branched chain amino acids | Males | (mg/d) | | Enriched, fortified, or whole-grain products; bread and bread products, mixed foods whose main ingredient is grain, and ready-to eat cereals
| | ≥31 yr | 1.2 | nd
| | Females
| | ≥31 yr | 1.1 | nd
Riboflavin | Coenzyme in numerous oxidation/reduction reactions | Males | (mg/d) | | Organ meats, milk, bread products and fortified cereals
| | ≥31 yr | 1.3 | nd
| | Females
| | ≥31 yr | 1.1 | nd
Vitamin B6 | Coenzyme in the metabolism of amino acids, glycogen and sphingolipid bases | Males | (mg/d) | | Fortified cereals, organ meats, fortified soy-based meat substitutes
Comprises a group of 3 vitamers: pyridoxal, pyridoxine, pyridoxamine; and 5′-phosphate coenzymes of each vitamer | | 31–50 yr | 1.3 | 100
| | ≥50 yr | 1.7 | 100
| | Females
| | 31–50 yr | 1.3 | 100
| | ≥50 yr | 1.5 | 100
Vitamin B12 | Coenzyme in amino acid and organic acid metabolism; prevents megaloblastic anemia | Males | (μg/d) | | Fortified cereals, meat, fish, poultry
Including its coenzymes methylcobalamin and adenosylcobalamin | | ≥31 yr | 2.4 | nd
| | Females
| | ≥31 yr | 2.4 | nd
Folate | Coenzyme in the metabolism of nucleic and amino acids; prevents megaloblastic anemia | Males | (μg/d) | | Enriched cereal grains, grain products, and bread products; dark leafy vegetables
Note: Given as dietary folate equivalents (DFE). 1 DFE = 1 μg food folate = 0.6 μg of folic acid from fortified food or as a supplement consumed with food. | | ≥31 yr | 400 | 1000
| | Females
| | ≥31 yr | 400 | 1000

Derived from Institute of Medicine report accessed at www.iom.edu/Object.File/Master/7/296/0.pdf via www.nal.usda.gov/fnic/etext/000105.html (accessed July 27, 2005).

RDA = Recommended Daily Allowance; UL = Upper Limit.

a UL = The maximum level of daily nutrient intake that is likely to pose no risk of adverse effects. Unless otherwise specified, the UL represents total intake from food, water, and supplements. Due to lack of suitable data, ULs could not be established for thiamin, riboflavin, or vitamin B12. In the absence of ULs, extra caution may be warranted in consuming levels above recommended intakes.

Overall, the B vitamins are known to function in several anti-oxidant, anti-inflammatory mechanisms, along with nucleotide biosynthesis and nerve function. However, a complete understanding of the underlying mechanisms and the relationship between B vitamins and neurodegenerative disorders, however, is still lacking.

## Proposed Mechanisms of the Effect of Constituents in Berries on Age-Related Neurodegenerative Disorders

There is convincing epidemiological evidence suggesting that eating fruits and vegetables may reduce the risk of cardiovascular disease and many cancers.^28^ It has been hypothesized that these potential health benefits are due in part to the presence of antioxidant compounds in these foods. These beneficial compounds, such as carotenoids, vitamin C, vitamin E, polyphenols, and selenium, have been grouped together as dietary antioxidants. However, despite this grouping, these compounds can differ considerably from each another. Other non-antioxidant nutrients in fruits and vegetables, such as fiber, potassium and folate, have also been associated with several beneficial health effects.^28^ The discussion of primary constituents in berries being considered regarding an effect on neurocognitive function is in the Results chapter, in response to the berries Key Question 1 regarding this topic.

Briefly, there is considerable research demonstrating the increased susceptibility of the aging brain to both oxidative stress and inflammation.^29^ Data from animal and in vitro studies suggests that among the many sources of antioxidants, phytochemicals (flavonoids, phenolic acids and terpenes, derived from plants) have a beneficial role with respect to brain aging and neurodegenerative disorders through the combination of their anti-oxidative, anti-inflammatory, anti-viral, anti-proliferative, and anti-carcinogenic properties.^30^ Since oxidative stress and inflammation appear to be involved in brain aging and in neurodegenerative disease states,^29^ it is theorized that increased consumption of antioxidants may be effective in preventing or ameliorating these changes.