# Appendix E. Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this Report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

- David Atkins, MD, MPH
- Chief Medical Officer
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- Tsunenobu Tamura, M.D
- Professor, Department of Nutrition Sciences
- Division of Molecular Nutrition & Genetics
- University of Alabama School of Health Related Professions
- Birmingham, AL

- Alice H. Lichtenstein, DSc
- Stanley N. Gershoff Professor of Nutrition Science and Policy
- Gerald J. and Dorothy R. Friedman School of Nutrition Science and Policy at Tufts University
- Senior Scientist, Director of the Cardiovascular Nutrition Laboratory
- Jean Mayer USDA Human Nutrition Research Center on Aging at Tufts University
- Boston, Massachusetts
- (Also a Technical Expert Panel member)
- Comments from the Office of Dietary Supplements, National Institutes of Health coordinated through

- Anne Thurn, PhD
- Director
- Evidence-Based Review Program
- Office of Dietary Supplements
- National Institutes of Health
- Bethesda, Maryland

- Ronald L. Prior, Ph.D.
- Agricultural Research Service Scientist
- United States Department of Agriculture
- Arkansas Children's Nutrition Center
- Little Rock, AR

- Nicholi Vorsa, PhD
- Research Professor
- Plant Science
- Marucci Blueberry-Cranberry Research Center Plant Science/Chatsworth
- Chatsworth, New Jersey
- (Also a Technical Expert Panel member)

- Henry W. Querfurth, MD, PhD
- Associate Professor of Neurology and Neuroscience
- Tufts University School of Medicine
- Chief, Neurology Research
- Caritas St. Elizabeth's Medical Center
- Boston, Massachusetts
- (Also a Technical Expert Panel member)
- Other Technical Expert Panel members also provided oral feedback and recommendations.