# Appendix D. List of Excluded Studies

Abd ElGawad HM, Khalifa AE. Quercetin, coenzyme Q10, and L-canavanine as protective agents against lipid peroxidation and nitric oxide generation in endotoxin-induced shock in rat brain. Pharmacol Res. 2001;43(3):257-63. Non-berry chemical. [pmid: 11401418].
Abe T, Itokawa Y. Effect of ethanol administration on thiamine metabolism and transketolase activity in rats. Int J Vitam Nutr Res. 1977;47(4):307-14. No outcome of interest. [pmid: 591201].
Abe T, Okamoto E, Itokawa Y. Biochemical and histological studies on thiamine-deficient and ethanol-fed rats. J Nutr Sci Vitaminol. 1979;25(5):375-83. No outcome of interest. [pmid: 396369].
Adachi K, Izumi M, Osano Y, Miura N, Takatsu S, Terao S, Mitsuma T. Polyamine concentrations in the brain of vitamin B12-deficient rats. Exp Biol Med. 2003;228(9):1069-71. No outcome of interest.
Agbayewa MO, Bruce VM, Siemens V. Pyridoxine, ascorbic acid and thiamine in Alzheimer and comparison subjects. Can J Psychiatry. 1992;37(9):661-2. N<50 (Food frequency questionnaire). [pmid: 1477827].
Ahmad Annuar A, Tabrizi SJ, Fisher EM. Mouse models as a tool for understanding neurodegenerative diseases. Curr Opin Neurol. 2003;16(4):451-8. Review. [pmid: 12869802].
Aikawa H, Suzuki K, Iwasaki Y. Ultrastructural observation on the thalamic neuronal inclusions in young mice. Acta Neuropathol. 1983;59(4):316-8. B vitamin antagonist. [pmid: 6306980].
Akaike A, Tamura Y, Sato Y, Yokota T. Protective effects of a vitamin B12 analog, methylcobalamin, against glutamate cytotoxicity in cultured cortical neurons. Eur J Pharmacol. 1993;241(1):1-6. No outcome of interest. [pmid: 7901032].
Almaas R, Saugstad OD, Pleasure D, Rootwelt T. Neuronal formation of free radicals plays a minor role in hypoxic cell death in human NT2-N neurons. Pediatr Res. 2002;51(2):136-43. Non-berry chemical. [pmid: 11809906].
Almeida OP, Flicker L, Lautenschlager NT, Leedman P, Vasikaran S, van Bockxmeer FM. Contribution of the MTHFR gene to the causal pathway for depression, anxiety and cognitive impairment in later life. Neurobiol Aging. 2005;26(2):251-7. All normal cognition (correlation study). [pmid: 15582752].
Amanpreet S, Naidu PS, Kulkarni SK. Quercetin potentiates L-dopa reversal of drug-induced catalepsy in rats: possible COMT/MAO inhibition. Pharmacology. 2003. Non-berry chemical
Anderson C, Checkoway H, Franklin GM, Beresford S, SmithWeller T, Swanson PD. Dietary factors in Parkinson's disease: the role of food groups and specific foods. Mov Disord. 1999;14(1):21-7. Fruit, not berry. [pmid: 9918340].
Andersson J, Gustafsson K, Fjellstrom C, Sidenvall B, Nydahl M. Five-day food intake in elderly female outpatients with Parkinson's disease, rheumatoid arthritis or stroke. J Nutr Health Aging. 2005. No comparison group (Food frequency questionnaire)
Armstrong James M, Ross DT, Chen F, Ebner FF. The effect of thiamine deficiency on the structure and physiology of the rat forebrain. Metab Brain Dis. 1988;3(2):91-124. No outcome of interest. [pmid: 2460728].
Bambauer HJ, Ueno S, Umar H, Ueck M. Ultracytochemical localization of Ca++-ATPase activity in pituicytes of the neurohypophysis of the guinea pig. Cell Tissue Res. 1984;237(3):491-7. Non-berry chemical. [pmid: 6237726].
Barbato M, Rodriguez PJ. Thiamine deficiency in patients admitted to a palliative care unit. Palliat Med. 1994;8(4):320-4. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 7529104].
Beal MF, Henshaw DR, Jenkins BG, Rosen BR, Schulz JB. Coenzyme Q10 and nicotinamide block striatal lesions produced by the mitochondrial toxin malonate. Ann Neurol. 1994;36(6):882-8. Wrong model (mitochondrial defect). [pmid: 7998775].
Bell IR, Edman JS, Marby DW, Satlin A, Dreier T, Liptzin B, Cole JO. Vitamin B12 and folate status in acute geropsychiatric inpatients: affective and cognitive characteristics of a vitamin nondeficient population. Biol Psychiatry. 1990;27(2):125-37. N<30 dementia (B12 or Folate correlation). [pmid: 2294976].
Bell IR, Edman JS, Miller J, Hebben N, Linn RT, Ray D, Kayne HL. Relationship of normal serum vitamin B12 and folate levels to cognitive test performance in subtypes of geriatric major depression. J Geriatr Psychiatry Neurol. 1990;3(2):98-105. N<100 (B12 or Folate correlation). [pmid: 2206265].
Bettendorff L, Hennuy B, De Clerck A, Wins P. Chloride permeability of rat brain membrane vesicles correlates with thiamine triphosphate content. Brain Res. 1994;652(1):157-60. No outcome of interest. [pmid: 7953714].
Bettendorff L, Hennuy B, Wins P, Schoffeniels E. Thiamin and derivatives as modulators of rat brain chloride channels. Neuroscience. 1993;52(4):1009-17. No outcome of interest. [pmid: 7680796].
Bettendorff L, Kolb HA, Schoffeniels E. Thiamine triphosphate activates an anion channel of large unit conductance in neuroblastoma cells. J Membr Biol. 1993;136(3):281-8. No outcome of interest. [pmid: 8114078].
Bettendorff L, Mastrogiacomo F, Wins P, Kish SJ, Grisar T, Ball MJ. Low thiamine diphosphate levels in brains of patients with frontal lobe degeneration of the non-Alzheimer's type. J Neurochem. 1997;69(5):2005-10. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 9349545].
Bettendorff L, Wins P, Schoffeniels E. Regulation of ion uptake in membrane vesicles from rat brain by thiamine compounds. Biochem Biophys Res Commun. 1990;171(3):1137-44. No outcome of interest. [pmid: 2222433].
Bhagavan HN, Stewart CN. Tissue pyridoxal-5′-phosphate content and avoidance behavior in 2-deoxypyridoxine-treated rats. Int J Vitam Nutr Res. 1974. B vitamin antagonist
Bhattacharya R, Lakshmana Rao PV. Pharmacological interventions of cyanide-induced cytotoxicity and DNA damage in isolated rat thymocytes and their protective efficacy in vivo. Toxicol Lett. 2001;119(1):59-70. Non-berry chemical. [pmid: 11275422].
Bickford P. Motor learning deficits in aged rats are correlated with loss of cerebellar noradrenergic function. Brain Res. 1993;620(1):133-8. Non-berry. [pmid: 8402185].
Botez MI, Botez T, Maag U. The Wechsler subtests in mild organic brain damage associated with folate deficiency. Psychol Med. 1984;14(2):431-7. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 6739633].
Bottiglieri T, Parnetti L, Arning E, Ortiz T, Amici S, Lanari A, Gallai V. Plasma total homocysteine levels and the C677T mutation in the methylenetetrahydrofolate reductase (MTHFR) gene: a study in an Italian population with dementia. Mech Ageing Dev. 2001;122(16):2013-23. N<100 (B12 or Folate correlation). [pmid: 11589919].
Brown I. Does diet protect against Parkinson's disease? Part 3 - Fruit, vegetables and grains. Nutr Food Sci. 2004. Review
Bunce D, Kivipelto M, Wahlin A. Apolipoprotein e, B vitamins, and cognitive function in older adults. J Gerontol B Psychol Sci Soc Sci. 2005;60(1):P41-8. All normal cognition (correlation study). [pmid: 15643038].
Bunce D, Kivipelto M, Wahlin A. Utilization of cognitive support in episodic free recall as a function of apolipoprotein E and vitamin B12 or folate among adults aged 75 years and older. Neuropsychology. 2004;18(2):362-70. All normal cognition (correlation study). [pmid: 15099158].
Buxton PK, Davison W, Hyams DE, Irvine WJ. Vitamin B12 status in mentally disturbed elderly patients. Gerontol Clin. 1969;11(1):22-35. N<100 (B12 or Folate correlation).
Calhau C, Martel F, SoaresdaSilva P, HipolitoReis C, Azevedo I. Regulation of [(3)H]MPP(+) transport by phosphorylation/dephosphorylation pathways in RBE4 cells: role of ecto-alkaline phosphatase. Naunyn-Schmiedebergs Arch Pharmacol. 2002;365(5):349-56. Non-berry chemical. [pmid: 12012020].
Calingasan NY, Baker H, Sheu KF, Gibson GE. Blood-brain barrier abnormalities in vulnerable brain regions during thiamine deficiency. Exp Neurol. 1995;134(1):64-72. B vitamin antagonist. [pmid: 7672039].
Calingasan NY, Park LC, Gandy SE, Gibson GE. Disturbances of the blood-brain barrier without expression of amyloid precursor protein- containing neuritic clusters or neuronal loss during late stages of thiamine deficiency in guinea pigs. Dev Neurosci. 1998. B vitamin antagonist
Campbell WA, Iskandar MK, Reed ML, Xia W. Endoproteolysis of presenilin in vitro: inhibition by gamma-secretase inhibitors. Biochemistry. 2002;41(10):3372-9. Not B vitamin study. [pmid: 11876645].
Cao G, Shukitt-Hale B, Bickford PC, Joseph JA, McEwen J, Prior RL. Hyperoxia-induced changes in antioxidant capacity and the effect of dietary antioxidants. J Appl Physiol. 1999 Jun. Non-berry chemical
Carlson RO, Aschmies SH. Tyrosine kinase activity is essential for interleukin-1 beta—stimulated production of interleukin-6 in U373 human astrocytoma cells. J Neurochem. 1995;65(6):2491-9. Non-berry chemical. [pmid: 7595543].
Casadesus G, ShukittHale B, Joseph JA. Qualitative versus quantitative caloric intake: are they equivalent paths to successful aging? Neurobiol Aging. 2002;23(5):747-69. Review.
Chan DK, Woo J, Ho SC, Pang CP, Law LK, Ng PW, Hung WT, Kwok T, Hui E, Orr K, Leung MF, Kay R. Genetic and environmental risk factors for Parkinson's disease in a Chinese population. J Neurol Neurosurg Psychiatry. 1998;65(5):781-4. Fruit, not berry. [pmid: 9810958]. [pmcid: 2170330].
Chan P, Cheng JT, Tsai JC, Lien GS, Chen FC, Kao PF, Liu JC, Chen YJ, Hsieh MH. Effect of catechin on the activity and gene expression of superoxide dismutase in cultured rat brain astrocytes. Neurosci Lett. 2002;328(3):281-4. Non-berry chemical. [pmid: 12147326].
Chen CJ, Raung SL, Liao SL, Chen SY. Inhibition of inducible nitric oxide synthase expression by baicalein in endotoxin/cytokine-stimulated microglia. Biochem Pharmacol. 2004;67(5):957-65. Non-berry chemical. [pmid: 15104249].
Cho J, Lee HK. Wogonin inhibits ischemic brain injury in a rat model of permanent middle cerebral artery occlusion. Biol Pharm Bull. 2004;27(10):1561-4. Non-berry chemical. [pmid: 15467195].
Choi E, Chee K, Choi M. The anti- and pro-oxidative effects of orally administered flavonoids in normal rats. Nutr Sci. 2004. Non-berry chemical
Cole MG, Prchal JF. Low serum vitamin B12 in Alzheimer-type dementia. Age Ageing. 1984;13(2):101-5. N<100 (B12 or Folate correlation). [pmid: 6731164].
Collins RC, Kirkpatrick JB, McDougal DB. Some regional pathologic and metabolic consequences in mouse brain of pyrithiamine-induced thiamine deficiency. J Neuropathol Exp Neurol. 1970;29(1):57-69. B vitamin antagonist. [pmid: 5411622].
Commenges D, Scotet V, Renaud S, JacqminGadda H, BarbergerGateau P, Dartigues JF. Intake of flavonoids and risk of dementia. Eur J Epidemiol. 2000;16(4):357-63. Non-berry chemical. [pmid: 10959944].
Conklin DR, Tan KH, Aschner M. Dimethyl sulfoxide, but not acidosis-induced metallothionein mRNA expression in neonatal rat primary astrocyte cultures is inhibited by the bioflavonoid, quercetin. Brain Res. 1998;794(2):304-8. Non-berry chemical. [pmid: 9622659].
Conte A, Pellegrini S, Tagliazucchi D. Effect of resveratrol and catechin on PC12 tyrosine kinase activities and their synergistic protection from beta-amyloid toxicity. Drugs Exp Clin Res. 2003;29(56):243-55. Non-berry chemical. [pmid: 15134381].
Conte A, Pellegrini S, Tagliazucchi D. Synergistic protection of PC12 cells from beta-amyloid toxicity by resveratrol and catechin. Brain Res Bull. 2003;62(1):29-38. Non-berry chemical. [pmid: 14596889].
Cowen MA, Green M, Bertollo DN, Abbott K. A treatment for tardive dyskinesia and some other extrapyramidal symptoms.[see comment]. J Clin Psychopharmacol. 1997;17(3):190-3. Combination B vitamin and other treatments. [pmid: 9169964].
Cunha UG. An investigation of dementia among elderly outpatients. Acta Psychiatr Scand. 1990;82(3):261-3. No B vitamin results. [pmid: 2248054].
Cyrino LA, Cardoso RC, Hackl LP, Nicolau M. Effect of quercetin on plasma extravasation in rat CNS and dura mater by ACE and NEP inhibition. Phytother Res. 2002;16(6):545-9. Non-berry chemical. [pmid: 12237812].
Dajas F, Rivera F, Blasina F, Arredondo F, Echeverry C, Lafon L, Morquio A, Heizen H. Cell culture protection and in vivo neuroprotective capacity of flavonoids. Neurotox Res. 2003;5(6):425-32. Non-berry chemical. [pmid: 14715446].
Dajas F, RiveraMegret F, Blasina F, Arredondo F, AbinCarriquiry JA, Costa G, Echeverry C, Lafon L, Heizen H, Ferreira M, Morquio A. Neuroprotection by flavonoids. Braz J Med Biol Res. 2003;36(12):1613-20. Review. [pmid: 14666245].
Davies J, Watkins JC. Facilitatory and direct excitatory effects of folate and folinate on single neurones of cat cerebral cortex. Biochem Pharmacol. 1973;22(13):1667-8. No outcome of interest. [pmid: 4542335].
Davis CW. Assessment of selective inhibition of rat cerebral cortical calcium-independent and calcium-dependent phosphodiesterases in crude extracts using deoxycyclic AMP and potassium ions. Biochim Biophys Acta. 1984;797(3):354-62. Non-berry chemical. [pmid: 6320906].
de Luis DA, Fernandez N, Arranz M, Aller R, Izaola O. Total homocysteine and cognitive deterioration in people with type 2 diabetes. Diabetes Res Clin Pract. 2002;55(3):185-90. N<100 (B12 or Folate correlation). [pmid: 11850094].
de Rijk MC, Breteler MM, den Breeijen JH, Launer LJ, Grobbee DE, van der Meche FG, Hofman A. Dietary antioxidants and Parkinson disease. The Rotterdam Study. Arch Neurol. 1997;54(6):762-5. Non-berry chemical. [pmid: 9193212].
De Ruvo C, Amodio R, Algeri S, Martelli N, Intilangelo A, D'Ancona GM, Esposito E. Nutritional antioxidants as antidegenerative agents. Int J Dev Neurosci. 2000;18(45):359-66. Non-berry chemical. [pmid: 10817920].
Dekermendjian K, Kahnberg P, Witt MR, Sterner O, Nielsen M, Liljefors T. Structure-activity relationships and molecular modeling analysis of flavonoids binding to the benzodiazepine site of the rat brain GABA(A) receptor complex. J Med Chem. 1999;42(21):4343-50. Non-berry chemical. [pmid: 10543878].
Diboune M, Ferard G, Ingenbleek Y, Bourguignat A, Spielmann D, SchepplerRoupert C, Tulasne PA, Calon B, Hasselmann M, Sauder P, Glasser N, Metais P. Soybean oil, blackcurrant seed oil, medium-chain triglycerides, and plasma phospholipid fatty acids of stressed patients. Nutrition. 1993. No outcomes of interest
Dines KC, Cotter MA, Cameron NE. Effectiveness of natural oils as sources of gamma-linolenic acid to correct peripheral nerve conduction velocity abnormalities in diabetic rats: modulation by thromboxane A2 inhibition. Prostaglandins Leukot Essent Fatty Acids. 1996;55(3):159-65. Non-berry. [pmid: 8931113].
Dufouil C, Alperovitch A, Ducros V, Tzourio C. Homocysteine, white matter hyperintensities, and cognition in healthy elderly people. Ann Neurol. 2003;53(2):214-21. No B vitamin results. [pmid: 12557288].
Durga J. Folate and age-related disease. Folate and age-related disease. 2005. Thesis
Duvoisin RC, Yahr MD, Cote LD. Pyridoxine reversal of L-dopa effects in Parkinsonism. Trans Am Neurol Assoc. 1969;94:81-4. Pyridoxine and L-Dopa effect. [pmid: 5374494].
Eastley R, Wilcock GK, Bucks RS. Vitamin B12 deficiency in dementia and cognitive impairment: the effects of treatment on neuropsychological function. Int J Geriatr Psychiatry. 2000;15(3):226-33. Retrospective intervention. [pmid: 10713580].
Ebly EM, Schaefer JP, Campbell NR, Hogan DB. Folate status, vascular disease and cognition in elderly Canadians. Age Ageing. 1998;27(4):485-91. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 9884006].
Elliott P, HooverPlow J. Excess dietary vitamin B6 alters water maze performance in two strains of mice. Nutr Res. 1989. Model of genetic B6 disorder
End DW, Look RA, Shaffer NL, Balles EA, Persico FJ. Non-selective inhibition of mammalian protein kinases by flavinoids in vitro. Res Commun Chem Pathol Pharmacol. 1987;56(1):75-86. Non-berry chemical. [pmid: 3495834].
Engelhart MJ, Geerlings MI, Ruitenberg A, van Swieten JC, Hofman A, Witteman JC, Breteler MM. Dietary intake of antioxidants and risk of Alzheimer disease. JAMA. 2002;287(24):3223-9. Non-berry chemical. [pmid: 12076218].
Essama Tjani JC, Guilland JC, Potier dC, Fuchs F, Richard D. Folate status worsens in recently institutionalized elderly people without evidence of functional deterioration. J Am Coll Nutr. 2000. No B vitamin results
Fahn S. ‘On-off’ phenomenon with levodopa therapy in Parkinsonism. Clinical and pharmacologic correlations and the effect of intramuscular pyridoxine. Neurology. 1974;24(5):431-41. Pyridoxine and L-Dopa effect. [pmid: 4857104].
Farina E, Pomati S, Mariani C. Observations on dementias with possibly reversible symptoms. Aging Clin Exp Res. 1999;11(5):323-8. No B vitamin results.
Feng R, He W, Ochi H. A new murine oxidative stress model associated with senescence. Mech Ageing Dev. 2001;122(6):547-59. Non-berry chemical. [pmid: 11295171].
Ferriola PC, Cody V, Middleton E Jr. Protein kinase C inhibition by plant flavonoids. Kinetic mechanisms and structure-activity relationships. Biochem Pharmacol. 1989;38(10):1617-24. Non-berry chemical. [pmid: 2730676].
Fischer P, Gotz ME, Ellinger B, Streifler M, Riederer P, Danielczyk W. Platelet monoamine oxidase B activity and vitamin B12 in dementia. Biol Psychiatry. 1994;35(10):772-4. N<100 (B12 or Folate correlation). [pmid: 8043706].
Flicker L, Martins RN, Thomas J, Acres J, Taddei K, Norman P, Jamrozik K, Almeida OP. Homocysteine, Alzheimer genes and proteins, and measures of cognition and depression in older men. J Alzheimers Dis. 2004;6(3):329-36. No B vitamin results. [pmid: 15201487].
Forti P, Maioli F, Nesi B, Vettori C, Flisi E, Dalmonte E, Zanardi V, Lodi L, Macini P, Caldarera M, Ravaglia G. Conselice study: a population based survey of brain aging in a municipality of the Emilia Romagna region: (A.U.S.L. Ravenna), neuropsychological tests and nutritional status. Arch Gerontol Geriatr. 2005. N<100 (B12 or Folate correlation)
Franchi F, Baio G, Bolognesi AG, Bonassi R, Emiliani S, Gobbi G, Luchetti L, Zurla L. Deficient folate nutritional status and cognitive performances: results from a retrospective study in male elderly inpatients in a geriatric department. Arch Gerontol Geriatr. 2005. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease)
Freeman GB, Nielsen PE, Gibson GE. Effect of age on behavioral and enzymatic changes during thiamin deficiency. Neurobiol Aging. 1987;8(5):429-34. B vitamin antagonist. [pmid: 3683723].
Freemon FR. Evaluation of patients with progressive intellectual deterioration. Arch Neurol. 1976;33(9):658-9. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 134683].
Gaitonde MK. Decreased turnover of N-acetylaspartate in the brain of thiamine-deficient rats. J Neurochem. 1979;32(5):1603-4. No outcome of interest. [pmid: 438827].
Gale JM, Brosemer RW. Effect of pyrithiamine treatment on potassium ion fluxes in rat cortical slices. Biochim Biophys Acta. 1984;773(1):125-31. B vitamin antagonist. [pmid: 6733091].
Galli RL, ShukittHale B, Youdim KA, Joseph JA. Fruit polyphenolics and brain aging: nutritional interventions targeting age-related neuronal and behavioral deficits. Ann N Y Acad Sci. 2002;959:128-32. Review. [pmid: 11976192].
Gallucci M, Zanardo A, De Valentin L, Vianello A. Homocysteine in Alzheimer disease and vascular dementia. Arch Gerontol Geriatr Suppl. 2005;(9):195–200. No B vitamin results
Gelinas S, Martinoli MG. Neuroprotective effect of estradiol and phytoestrogens on MPP+-induced cytotoxicity in neuronal PC12 cells. J Neurosci Res. 2002;70(1):90-6. Non-berry chemical. [pmid: 12237867].
Ghandour H, Chen Z, Selhub J, Rozen R. Mice deficient in methylenetetrahydrofolate reductase exhibit tissue-specific distribution of folates. J Nutr. 2004;134(11):2975-8. No outcome of interest. [pmid: 15514261].
Gibson G, Nielsen P, Mykytyn V, Carlson K, Blass J. Regionally selective alterations in enzymatic activities and metabolic fluxes during thiamin deficiency. Neurochem Res. 1989;14(1):17-24. No outcome of interest. [pmid: 2496326].
Gibson GE, Calingasan NY, Baker H, Gandy S, Sheu KF. Importance of vascular changes in selective neurodegeneration with thiamine deficiency. Ann N Y Acad Sci. 1997;826:516-9. Review. [pmid: 9329737].
Gibson GE, KsiezakReding H, Sheu KF, Mykytyn V, Blass JP. Correlation of enzymatic, metabolic, and behavioral deficits in thiamin deficiency and its reversal. Neurochem Res. 1984;9(6):803-14. B vitamin antagonist. [pmid: 6149477].
Giem P, Beeson WL, Fraser GE. The incidence of dementia and intake of animal products: preliminary findings from the Adventist Health Study. Neuroepidemiology. 1993;12(1):28-36. Non-berry. [pmid: 8327020].
Glaso M, Nordbo G, Diep L, Bohmer T. Reduced concentrations of several vitamins in normal weight patients with late-onset dementia of the Alzheimer type without vascular disease. J Nutr Health Aging. 2005;8(5):407-13. N<100 (B12 or Folate correlation).
Gomes-Trolin C, Gottfries CG, Regland B, Oreland L. Influence of vitamin B12 on brain methionine adenosyltransferase activity in senile dementia of the Alzheimer's type. J Neural Transm. 1996;103(7):861-72. No outcome of interest. [pmid: 8872870].
Gomes-Trolin C, Regland B, Oreland L. Decreased methionine adenosyltransferase activity in erythrocytes of patients with dementia disorders. Eur Neuropsychopharmaco. 1995;5(2):107-14. No outcome of interest.
Grabow JD, Linkswiler H. Electroencephalographic and nerve-conduction studies in experimental vitamin B 6 deficiency in adults. Am J Clin Nutr. 1969;22(11):1429-34. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 5356511].
Greer A, McBride DH, Shenkin A. Comparison of the nutritional state of new and long-term patients in a psychogeriatric unit. Br J Psychiatry. 1986;149:738-41. No outcome of interest. [pmid: 3098334].
Gu ZL, Xiao D, Jin LQ, Fan PS, Qian ZN. Effects of quercetin on Na(+)-K(+)-exchanging ATPase and Ca(2+) Mg(2+)-ATPase in rats. Chung Kuo Yao Li Hsueh Pao. 1994;15(5):414-6. Non-berry chemical. [pmid: 7717064].
Guilarte TR. Reduced NMDA receptor-ion channel function in the vitamin B-6 restricted neonatal rat brain. Neurosci Lett. 1991;121(12):207-10. No outcome of interest. [pmid: 1708479].
Gupta R, Singh M, Sharma A. Neuroprotective effect of antioxidants on ischaemia and reperfusion-induced cerebral injury. Pharmacol Res. 2003;48(2):209-15. Non-berry chemical. [pmid: 12798674].
Ha HJ, Kwon YS, Park SM, Shin T, Park JH, Kim HC, Kwon MS, Wie MB. Quercetin attenuates oxygen-glucose deprivation- and excitotoxin-induced neurotoxicity in primary cortical cell cultures. Biol Pharm Bull 26(4):544–6. 2003 Non-berry chemical
Hakim AM. Effect of thiamine deficiency and its reversal on cerebral blood flow in the rat. Observations on the phenomena of hyperperfusion, ‘no reflow,’ and delayed hypoperfusion. J Cereb Blood Flow Metab. 1986;6(1):79-85. No outcome of interest. [pmid: 3944219].
Haller J, Weggemans RM, Ferry M, Guigoz Y. Mental health: minimental state examination and geriatric depression score of elderly Europeans in the SENECA study of 1993. Eur J Clin Nutr. 1996. All normal cognition (correlation study)
Halliwell B. Antioxidant activity and other biological effects of flavonoids. International Congress and Symposium Series - Royal Society of Medicine. 2000. Review
Hancock MR, Hullin RP, Aylard PR, King JR, Morgan DB. Nutritional state of elderly women on admission to mental hospital. Br J Psychiatry. 1985;147:404-7. Combination B vitamin and other treatments. [pmid: 4075030].
Hannum SM. Potential impact of strawberries on human health: a review of the science. Crit Rev Food Sci Nutr. 2004;44(1):1-17. Review. [pmid: 15077879].
Harata N, Iwasaki Y. Evidence for early blood-brain barrier breakdown in experimental thiamine deficiency in the mouse. Metab Brain Dis. 1995;10(2):159-74. B vitamin antagonist. [pmid: 7675014].
Hassing L, Wahlin A, Winblad B, Backman L. Further evidence on the effects of vitamin B12 and folate levels on episodic memory functioning: a population-based study of healthy very old adults. Biol Psychiatry. 1999;45(11):1472-80. N<100 (B12 or Folate correlation). [pmid: 10356630].
Hatta S, Watanabe M, Ikeda H, Kamada H, Saito T, Ohshika H. Impairment of adenylyl cyclase signal transduction in mecobalamin-deficient rats. Eur J Pharmacol. 1995;291(3):351-8. No outcome of interest. [pmid: 8719420].
Healton EB, Savage DG, Brust JC, Garrett TJ, Lindenbaum J. Neurologic aspects of cobalamin deficiency. Medicine. 1991;70(4):229-45. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 1648656].
Hellenbrand W, Seidler A, Boeing H, Robra BP, Vieregge P, Nischan P, Joerg J, Oertel WH, Schneider E, Ulm G. Diet and Parkinson's disease. I: A possible role for the past intake of specific foods and food groups. Results from a self-administered food-frequency questionnaire in a case-control study. Neurology. 1996;47(3):636-43. Fruit, not berry. [pmid: 8797456].
Hendriks JJ, de Vries HE, van der Pol SM, van den Berg TK, van Tol EA, Dijkstra CD. Flavonoids inhibit myelin phagocytosis by macrophages, a structure-activity relationship study. Biochem Pharmacol. 2003;65(5):877-85. Non-berry chemical. [pmid: 12628496].
Heseker H, Kubler W, Pudel V, Westenhofer J. Interaction of vitamins with mental performance. Bibl Nutr Dieta. 1995;(52):43–55. Combination B vitamin and other treatments
Ho PI, Ashline D, Dhitavat S, Ortiz D, Collins SC, Shea TB, Rogers E. Folate deprivation induces neurodegeneration: roles of oxidative stress and increased homocysteine. Neurobiol Dis. 2003;14(1):32-42. No outcome of interest. [pmid: 13678664].
Hollman PC, Katan MB. Health effects and bioavailability of dietary flavonols. Free Radic Res. 1999;31(Suppl):S75-80. Review. [pmid: 10694044].
Homewood J, Bond NW, McGregor JC. The effects of chronic alcohol consumption or thiamin deficiency on radial-arm maze performance in the rat. Alcohol. 1991;8(4):265-72. Not B vitamin study. [pmid: 1872987].
Homewood. The effects of chronic alcohol consumption or thiamin deficiency on radial-arm maze performance in the rat. Alcohol. 1991;8(4):265-72. B vitamin antagonist. [pmid: 1872987].
Houzen H, Kanno M. Thiamine and its derivatives inhibit delayed rectifier potassium channels of rat cultured cortical neurons. Neuropharmacology. 1998;37(3):313-22. No outcome of interest. [pmid: 9681929].
Hsu TH, Bianchine JR, Preziosi TJ, Messiha FS. Effect of pyridoxine on levodopa metabolism in normal and parkinsonian subjects. Proc Soc Exp Biol Med. 1973;143(2):578-81. Pyridoxine and L-Dopa effect. [pmid: 4709027].
Huang MT, Lysz T, Ferraro T, Abidi TF, Laskin JD, Conney AH. Inhibitory effects of curcumin on in vitro lipoxygenase and cyclooxygenase activities in mouse epidermis. Cancer Res. 1991;51(3):813-9. Non-berry chemical. [pmid: 1899046].
Hung SC, Hung SH, Tarng DC, Yang WC, Chen TW, Huang TP. Thiamine deficiency and unexplained encephalopathy in hemodialysis and peritoneal dialysis patients. Am J Kidney Dis. 2001;38(5):941-7. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 11684545].
Ikeda T, Furukawa Y, Mashimoto S, Takahashi K, Yamada M. Vitamin B12 levels in serum and cerebrospinal fluid of people with Alzheimer's disease. Acta Psychiatr Scand. 1990;82(4):327-9. N<100 (B12 or Folate correlation). [pmid: 2260490].
Inanami O, Watanabe Y, Syuto B, Nakano M, Tsuji M, Kuwabara M. Oral administration of (-)catechin protects against ischemia-reperfusion-induced neuronal death in the gerbil. Free Radic Res. 1998;29(4):359-65. Non-berry chemical. [pmid: 9860051].
Irle E, Markowitsch HJ. Thiamine deficiency in the cat leads to severe learning deficits and to widespread neuroanatomical damage. Exp Brain Res. 1982;48(2):199-208. B vitamin antagonist. [pmid: 7173357].
Ishige K, Schubert D, Sagara Y. Flavonoids protect neuronal cells from oxidative stress by three distinct mechanisms. Free Radic Biol Med. 2001;30(4):433-46. Non-berry chemical. [pmid: 11182299].
Je HD, Shin CY, Park SY, Yim SH, Kum C, Huh IH, Kim JH, Sohn UD. Combination of vitamin C and rutin on neuropathy and lung damage of diabetes mellitus rats. Arch Pharm Res. 2002;25(2):184-90. Non-berry chemical. [pmid: 12009033].
Jelicic M, Jonker C, Deeg DJ. Effect of low levels of serum vitamin B12 and folic acid on cognitive performance in old age: a population-based study. Dev Neuropsychol. 2002. All normal cognition (correlation study)
Ji XD, Melman N, Jacobson KA. Interactions of flavonoids and other phytochemicals with adenosine receptors. J Med Chem. 1996;39(3):781-8. Non-berry chemical. [pmid: 8576921].
Jones JM. Nutrition. Cereal Foods World. 2003. Review
Joseph JA, Denisova N, Fisher D, Bickford P, Prior R, Cao G. Age-related neurodegeneration and oxidative stress: putative nutritional intervention. Neurol Clin. 1998;16(3):747-55. Review. [pmid: 9666048].
Joseph JA, Denisova NA, Bielinski D, Fisher DR, ShukittHale B. Oxidative stress protection and vulnerability in aging: putative nutritional implications for intervention. Mech Ageing Dev. 2000;116(23):141-53. Review. [pmid: 10996014].
Joseph JA, Denisova NA, Bielinski D, Fisher DR, ShukittHale B. Oxidative stress protection and vulnerability in aging: putative nutritional implications for intervention. Mech Ageing Dev. 2000;116(23):141-53. Review. [pmid: 10996014].
Joseph JA, ShukittHale B, Casadesus G. Reversing the deleterious effects of aging on neuronal communication and behavior: beneficial properties of fruit polyphenolic compounds. Am J Clin Nutr. 2005;81(1 Suppl):313S-316S. Review. [pmid: 15640496].
Kang S, Lee J, Choi Y, Kim G, Han B. Neuroprotective effects of flavones on hydrogen peroxide-induced apoptosis in SH-SY5Y neuroblostoma cells. Bioorganic & Medicinal Chemistry Letters. 2004. Non-berry chemical
Kanski J, Aksenova M, Stoyanova A, Butterfield DA. Ferulic acid antioxidant protection against hydroxyl and peroxyl radical oxidation in synaptosomal and neuronal cell culture systems in vitro: structure-activity studies. J Nutr Biochem. 2002. Non-berry chemical
Karnaze DS, Carmel R. Low serum cobalamin levels in primary degenerative dementia. Do some patients harbor atypical cobalamin deficiency states? Arch Intern Med. 1987;147(3):429-31. N<100 (B12 or Folate correlation).
Karton Y, Jiang JL, Ji XD, Melman N, Olah ME, Stiles GL, Jacobson KA. Synthesis and biological activities of flavonoid derivatives as A3 adenosine receptor antagonists. J Med Chem. 1996;39(12):2293-301. Non-berry chemical. [pmid: 8691424].
Ke ZJ, DeGiorgio LA, Volpe BT, Gibson GE. Reversal of thiamine deficiency-induced neurodegeneration. J Neuropathol Exp Neurol. 2003;62(2):195-207. B vitamin antagonist. [pmid: 12578229].
Kim HS, Cho JY, Kim DH, Yan JJ, Lee HK, Suh HW, Song DK. Inhibitory effects of long-term administration of ferulic acid on microglial activation induced by intracerebroventricular injection of beta-amyloid peptide (1–42) in mice. Biol Pharm Bull. 2004;27(1):120-1. Non-berry chemical. [pmid: 14709913].
Klawans HL, Ringel SP, Shenker DM. Failure of vitamin B6 to reverse the L-dopa effect in patients on a dopa decarboxylase inhibitor. J Neurol Neurosurg Psychiatry. 1971;34(6):682-6. Retrospective intervention. [pmid: 5158783]. [pmcid: 1083502].
Knekt P, Kumpulainen J, Jarvinen R, Rissanen H, Heliovaara M, Reunanen A, Hakulinen T, Aromaa A. Flavonoid intake and risk of chronic diseases. Am J Clin Nutr. 2002;76(3):560-8. No outcomes of interest. [pmid: 12198000].
Ko HH, Yu SM, Ko FN, Teng CM, Lin CN. Bioactive constituents of Morus australis and Broussonetia papyrifera. J Nat Prod. 1997;60(10):1008-11. Non-berry. [pmid: 9358644].
Koehler KM, PareoTubbeh SL, Romero LJ, Baumgartner RN, Garry PJ. Folate nutrition and older adults: challenges and opportunities. J Am Diet Assoc. 1997;97(2):167-73. No outcome of interest. [pmid: 9020245].
Koh SH, Kim SH, Kwon H, Park Y, Kim KS, Song CW, Kim J, Kim MH, Yu HJ, Henkel JS, Jung HK. Epigallocatechin gallate protects nerve growth factor differentiated PC12 cells from oxidative-radical-stress-induced apoptosis through its effect on phosphoinositide 3-kinase/Akt and glycogen synthase kinase-3. Brain Res Mol Brain Res. 2003;118(12):72-81. Non-berry chemical. [pmid: 14559356].
Kong LD, Cheng CH, Tan RX. Inhibition of MAO A and B by some plant-derived alkaloids, phenols and anthraquinones. J Ethnopharmacol. 2004;91(23):351-5. Non-berry chemical. [pmid: 15120460].
Laurin D, Masaki KH, Foley DJ, White LR, Launer LJ. Midlife dietary intake of antioxidants and risk of late-life incident dementia: the Honolulu-Asia Aging Study. Am J Epidemiol. 2004;159(10):959-67. Non-berry chemical. [pmid: 15128608].
Leblhuber F, Walli J, ArtnerDworzak E, Vrecko K, Widner B, Reibnegger G, Fuchs D. Hyperhomocysteinemia in dementia. J Neural Transm. 2000;107(12):1469-74. N<100 (B12 or Folate correlation). [pmid: 11458999].
Lee L, Kang SA, Lee HO, Lee BH, Park JS, Kim JH, Jung IK, Park YJ, Lee JE. Relationships between dietary intake and cognitive function level in Korean elderly people. Public Health. 2001;115(2):133-8. Fruit, not berry. [pmid: 11406779].
Lee M, Lee K, Kim H, Hong S, Ro J. Inhibitory effects of coptisine on monoamine oxidase activity. Nat Prod Sci. 2000. Unable to retrieve
Leon AS, Spiegel HE, Thomas G, Abrams WB. Pyridoxine antagonism of levodopa in parkinsonism. JAMA. 1971;218(13):1924-7. Pyridoxine and L-Dopa effect. [pmid: 5171069].
Levinson BM. The blueberry syndrome. Psychol Rep. 1980;46(1):47-52. No outcomes of interest. [pmid: 7367553].
Levitt AJ, Karlinsky H. Folate, vitamin B12 and cognitive impairment in patients with Alzheimer's disease. Acta Psychiatr Scand. 1992;86(4):301-5. N<100 (B12 or Folate correlation). [pmid: 1456073].
Lin Y, Desbois A, Jiang S, Hou ST. Group B vitamins protect murine cerebellar granule cells from glutamate/NMDA toxicity. Neuroreport. 2004;15(14):2241-4. No outcome of interest. [pmid: 15371742].
Lin YM, Raffen R, Zhou Y, Cassidy CS, Flavin MT, Stevens FJ. Amyloid fibril formation in microwell plates for screening of inhibitors. Amyloid. 2001;8(3):182-93. Non-berry. [pmid: 11676295].
Lindboe CF, Loberg EM. Wernicke's encephalopathy in non-alcoholics. An autopsy study. J Neurol Sci. 1989;90(2):125-9. No outcome of interest. [pmid: 2723677].
Liu RH. Health benefits of fruit and vegetables are from additive and synergistic combinations of phytochemicals. Am J Clin Nutr. 2003;78(3 Suppl):517S-520S. Review. [pmid: 12936943].
Lopez OL, Becker JT, Klunk W, Saxton J, Hamilton RL, Kaufer DI, Sweet RA, Cidis MC, Wisniewski S, Kamboh MI, DeKosky ST. Research evaluation and diagnosis of possible Alzheimer's disease over the last two decades: II. Neurology. 2000;55(12):1863-9. No B vitamin results. [pmid: 11134386].
Lopponen M, Raiha I, Isoaho R, Vahlberg T, Kivela SL. Diagnosing cognitive impairment and dementia in primary health care — a more active approach is needed.[see comment]. Age Ageing. 2003;32(6):606-12. No outcome of interest. [pmid: 14600001].
Lorenz P, Roychowdhury S, Engelmann M, Wolf G, Horn TF. Oxyresveratrol and resveratrol are potent antioxidants and free radical scavengers: effect on nitrosative and oxidative stress derived from microglial cells. Nitric Oxide. 2003;9(2):64-76. Non-berry chemical. [pmid: 14623172].
Losi G, Puia G, Garzon G, de Vuono MC, Baraldi M. Apigenin modulates GABAergic and glutamatergic transmission in cultured cortical neurons. Eur J Pharmacol. 2004;502(12):41-6. Non-berry chemical. [pmid: 15464088].
Maguire TM, Breen KC. A decrease in neural sialyltransferase activity in Alzheimer's disease. Dementia. 1995;6(4):185-90. No B vitamin results. [pmid: 7550596].
Mair RG, Anderson CD, Langlais PJ, McEntee WJ. Behavioral impairments, brain lesions and monoaminergic activity in the rat following recovery from a bout of thiamine deficiency. Behav Brain Res. 1988;27(3):223-39. B vitamin antagonist. [pmid: 2896002].
Mair RG, Anderson CD, Langlais PJ, McEntee WJ. Thiamine deficiency depletes cortical norepinephrine and impairs learning processes in the rat. Brain Res. 1985;360(12):273-84. B vitamin antagonist. [pmid: 4075172].
Manz HJ, Robertson DM. Vascular permeability to horseradish peroxidase in brainstem lesions of thiamine-deficient rats. Am J Pathol. 1972;66(3):565-76. Immature rats. [pmid: 5060583]. [pmcid: 2032735].
Marengoni A, Cossi S, De Martinis M, Calabrese PA, Orini S, Grassi V. Homocysteine and disability in hospitalized geriatric patients. Metabolism. 2004;53(8):1016-20. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 15281011].
Mars H. Levodopa, carbidopa, and pyridoxine in Parkinson disease. Metabolic interactions. Arch Neurol. 1974;30(6):444-7. Pyridoxine and L-Dopa effect. [pmid: 4827061].
Mars H. Metabolic interactions of pyridoxine, levodopa, and carbidopa in Parkinson's disease. Trans Am Neurol Assoc. 1973;98:241-5. Pyridoxine and L-Dopa effect. [pmid: 4784941].
Martin A, Cherubini A, AndresLacueva C, Paniagua M, Joseph J. Effects of fruits and vegetables on levels of vitamins E and C in the brain and their association with cognitive performance. J Nutr Health Aging. 2002;6(6):392-404. Review. [pmid: 12459890].
Mastrogiacomo F, Bergeron C, Kish SJ. Brain alpha-ketoglutarate dehydrogenase complex activity in Alzheimer's disease. J Neurochem. 1993;61(6):2007-14. Not B vitamin study. [pmid: 8245957].
Mazzio EA, Harris N, Soliman KF. Food constituents attenuate monoamine oxidase activity and peroxide levels in C6 astrocyte cells. Planta Med. 1998;64(7):603-6. Non-berry chemical. [pmid: 9810264].
McCaddon A, Davies G, Hudson P, Tandy S, Cattell H. Total serum homocysteine in senile dementia of Alzheimer type. Int J Geriatr Psychiatry. 1998;13(4):235-9. N<100 (B12 or Folate correlation). [pmid: 9646150].
McCaddon A, Hudson P, Abrahamsson L, Olofsson H, Regland B. Analogues, ageing and aberrant assimilation of vitamin B12 in Alzheimer's disease. Dement Geriatr Cogn Disord. 2001;12(2):133-7. N<100 (B12 or Folate correlation). [pmid: 11173886].
McCaddon A, Kelly CL. Familial Alzheimer's disease and vitamin B12 deficiency. Age Ageing. 1994;23(4):334-7. N<100 (B12 or Folate correlation). [pmid: 7976784].
McGeer PL, Zeldowicz L, McGeer EG. A clinical trial of folic acid in Parkinson's disease. Can Med Assoc J. 1972;106(2):145-6. passim. No outcome of interest. [pmid: 4400558]. [pmcid: 1940357].
McKenna MC, Tildon JT, Stevenson JH, Hopkins IB, Huang X, Couto R. Lactate transport by cortical synaptosomes from adult rat brain: characterization of kinetics and inhibitor specificity. Dev Neurosci. 1920. Non-berry chemical
Meins W, MullerThomsen T, MeierBaumgartner HP. Subnormal serum vitamin B12 and behavioural and psychological symptoms in Alzheimer's disease. Int J Geriatr Psychiatry. 2000;15(5):415-8. N<100 (B12 or Folate correlation). [pmid: 10822240].
Melzig MF, Escher F. Induction of neutral endopeptidase and angiotensin-converting enzyme activity of SK-N-SH cells in vitro by quercetin and resveratrol. Pharmazie. 2002;57(8):556-8. Non-berry chemical. [pmid: 12227197].
Meydani M. Nutrition interventions in aging and age-associated disease. Ann N Y Acad Sci. 2001;928:226-35. Review. [pmid: 11795514].
Mihalick SM, Ortiz D, Kumar R, Rogers E, Shea TB. Folate and vitamin E deficiency impair cognitive performance in mice subjected to oxidative stress: differential impact on normal mice and mice lacking apolipoprotein E. Neuromolecular Med. 2003;4(3):197-202. Combination B vitamin and other treatments. [pmid: 14716026].
Miller JW, Green R, Ramos MI, Allen LH, Mungas DM, Jagust WJ, Haan MN. Homocysteine and cognitive function in the Sacramento Area Latino Study on Aging. Am J Clin Nutr. 2003;78(3):441-7. No B vitamin results. [pmid: 12936927].
Miller JW, Selhub J, Nadeau MR, Thomas CA, Feldman RG, Wolf PA. Effect of L-dopa on plasma homocysteine in PD patients: relationship to B-vitamin status. Neurology. 2003;60(7):1125-9. No outcome of interest. [pmid: 12682318].
Miller JW. Folate, cognition, and depression in the era of folic acid fortification. J Food Sci. 2005. Review
Milward EA, Grayson DA, Creasey H, Janu MR, Brooks WS, Broe GA. Evidence for association of anaemia with vascular dementia. Neuroreport. 1999;10(11):2377-81. No B vitamin results. [pmid: 10439467].
Molimard R, Marillaud A, Paille A, Le Devehat C, Lemoine A, Dougny M. Impairment of memorization by high doses of pyridoxine in man. Biomedicine. 1980;32(2):88-92. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 7388119].
MolinaJimenez MF, SanchezReus MI, Benedi J. Effect of fraxetin and myricetin on rotenone-induced cytotoxicity in SH-SY5Y cells: comparison with N-acetylcysteine. Eur J Pharmacol. 2003;472(12):81-7. Non-berry chemical. [pmid: 12860476].
Moretti R, Torre P, Antonello RM, Cazzato G, Cattaruzza T, Scapicchio PL. Vitamin B12 and folate depletion: clinical evidence in a neurological population. Neurologist. 2004;10(6):338-43. Review. [pmid: 15518600].
Murphy MP, Uljon SN, Golde TE, Wang R. FAD-linked mutations in presenilin 1 alter the length of Abeta peptides derived from betaAPP transmembrane domain mutants. Biochim Biophys Acta. 2002;1586(2):199-209. Not B vitamin study. [pmid: 11959461].
Murphy P, Sharp A, Shin J, Gavrilyuk V, Dello RC, Weinberg G, Sharp FR, Lu A, Heneka MT, Feinstein DL. Suppressive effects of ansamycins on inducible nitric oxide synthase expression and the development of experimental autoimmune encephalomyelitis. J Neurosci Res. 2002;67(4):461-70. Non-berry chemical. [pmid: 11835313].
Muthian G, Bright JJ. Quercetin, a flavonoid phytoestrogen, ameliorates experimental allergic encephalomyelitis by blocking IL-12 signaling through JAK-STAT pathway in T lymphocyte. J Clin Immunol. 2004. Non-berry chemical
Naidu PS, Kulkarni SK. Quercetin, a bioflavonoid, reverses haloperidol-induced catalepsy. Methods Find Exp Clin Pharmacol. 2004;26(5):323-6. Non-berry chemical. [pmid: 15319809].
Naidu PS, Singh A, Kulkarni SK. Quercetin, a bioflavonoid, attenuates haloperidol-induced orofacial dyskinesia. Neuropharmacology. 2003;44(8):1100-6. Non-berry chemical. [pmid: 12763102].
Naidu PS, Singh A, Kulkarni SK. Reversal of haloperidol-induced orofacial dyskinesia by quercetin, a bioflavonoid. Psychopharmacology. 2003;167(4):418-23. Non-berry chemical. [pmid: 12669184].
Naidu PS, Singh A, Kulkarni SK. Reversal of reserpine-induced orofacial dyskinesia and cognitive dysfunction by quercetin. Pharmacology. 2004;70(2):59-67. Non-berry chemical. [pmid: 14685008].
Nakata N, Kato H, Kogure K. Inhibition of ischaemic tolerance in the gerbil hippocampus by quercetin and anti-heat shock protein-70 antibody. Neuroreport. 1993;4(6):695-8. Non-berry chemical. [pmid: 8347809].
Nardini M, Leonardi F, Scaccini C, Virgili F. Modulation of ceramide-induced NF-kappaB binding activity and apoptotic response by caffeic acid in U937 cells: comparison with other antioxidants. Free Radic Biol Med. 2001;30(7):722-33. Non-berry chemical. [pmid: 11275472].
Nes M, Sem SW, Rousseau B, Bjorneboe GE, Engedal K, Trygg K, Pedersen JI. Dietary intakes and nutritional status of old people with dementia living at home in Oslo. Eur J Clin Nutr. 1988;42(7):581-93. N<100 (B12 or Folate correlation). [pmid: 3265665].
Nijst TQ, Wevers RA, Schoonderwaldt HC, Hommes OR, de Haan AF. Vitamin B12 and folate concentrations in serum and cerebrospinal fluid of neurological patients with special reference to multiple sclerosis and dementia. J Neurol Neurosurg Psychiatry. 1990;53(11):951-4. N<30 (dementia). [pmid: 2283525]. [pmcid: 488275].
Nilsson K, Gustafson L, Hultberg B. The plasma homocysteine concentration is better than that of serum methylmalonic acid as a marker for sociopsychological performance in a psychogeriatric population. Clinical Chemistry. 2000;46(5):691-6. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 10794752].
Nilsson K, Warkentin S, Hultberg B, Faldt R, Gustafson L. Treatment of cobalamin deficiency in dementia, evaluated clinically and with cerebral blood flow measurements. Aging Clin Exp Res. 2000;12(3):199-207. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease).
Ono K, Hasegawa K, Naiki H, Yamada M. Anti-amyloidogenic activity of tannic acid and its activity to destabilize Alzheimer's beta-amyloid fibrils in vitro. Biochim Biophys Acta. 2004;1690(3):193-202. Non-berry chemical. [pmid: 15511626].
Ortiz OE, Sjodin RA, Boyne A. ATP-dependent calcium accumulation by non-mitochondrial organelles of axoplasm isolated from Myxicola giant axons. Biochim Biophys Acta. 1985;814(1):13-22. Non-berry. [pmid: 3919764].
O'Suilleabhain PE, Sung V, Hernandez C, Lacritz L, Dewey RB, Bottiglieri T, DiazArrastia R. Elevated plasma homocysteine level in patients with Parkinson disease: motor, affective, and cognitive associations. Arch Neurol. 2004;61(6):865-8. No B vitamin results. [pmid: 15210523].
Pai TG, Suiko M, Sakakibara Y, Liu M. Sulfation of flavonoids and other phenolic dietary compounds by the human cytosolic sulfotransferases. Biochem Biophys Res Commun. 2001. Non-berry chemical
Pak KJ, Chan SL, Mattson MP. Homocysteine and folate deficiency sensitize oligodendrocytes to the cell death-promoting effects of a presenilin-1 mutation and amyloid beta-peptide. Neuromolecular Med. 2005;3(2):119-28. No outcome of interest.
Panneerselvam K, Balasubramanian AS. Lysosomal enzyme binding receptor protein from monkey brain and its phosphorylation. Indian J Biochem Biophys. 1991;28(56):395-400. Non-berry chemical. [pmid: 1667394].
Parnetti L, Mecocci P, Reboldi GP, Santucci C, Brunetti M, Gaiti A, Cadini D, Senin U. Platelet MAO-B activity and vitamin B12 in old age dementias. Mol Chem Neuropathol. 1992;16(12):23-32. N<100 (B12 or Folate correlation). [pmid: 1520404].
Patil CS, Singh VP, Satyanarayan PS, Jain NK, Singh A, Kulkarni SK. Protective effect of flavonoids against aging- and lipopolysaccharide-induced cognitive impairment in mice. Pharmacology. 2003;69(2):59-67. Non-berry chemical. [pmid: 12928578].
Pepersack T, Garbusinski J, Robberecht J, Beyer I, Willems D, Fuss M. Clinical relevance of thiamine status amongst hospitalized elderly patients. Gerontology. 1999;45(2):96-101. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 9933732].
Petri S, Petri C. Effect of vitamin B6 upon gastroprival central nervous system degenerations. 3. Acta Med Scand. 1970;187(12):129-31. No outcome of interest. [pmid: 5423201].
Pfeiffer R, Ebadi M. On the mechanism of the nullification of CNS effects of L-DOPA by pyridoxine in Parkinsonian patients. J Neurochem. 1972. No outcome of interest
Phillis JW, O'Regan MH. Evidence for swelling-induced adenosine and adenine nucleotide release in rat cerebral cortex exposed to monocarboxylate-containing or hypotonic artificial cerebrospinal fluids. Neurochem Int. 2002;(7):629–35. Non-berry chemical
Piantelli M, Rinelli A, Macri E, Maggiano N, Larocca LM, Scerrati M, Roselli R, Iacoangeli M, Scambia G, Capelli A. Type II estrogen binding sites and antiproliferative activity of quercetin in human meningiomas. Cancer. 1993;71(1):193-8. Non-berry chemical. [pmid: 8416715].
Picq M, Cheav SL, Prigent AF. Effect of two flavonoid compounds on central nervous system. Analgesic activity. Life Sci. 1991;49(26):1979-88. Non-berry chemical. [pmid: 1660953].
Picq M, Dubois M, MunariSilem Y, Prigent AF, Pacheco H. Flavonoid modulation of protein kinase C activation. Life Sci 44(21):1563–71. 1989. Non-berry chemical
Pirttila T, Salo J, Laippala P, Frey H. Effect of advanced brain atrophy and vitamin deficiency on cognitive functions in non-demented subjects. Acta Neurol Scand. 1993;87(2):161-6. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 8442398].
Posypanova GA, Severin SE, Kondratyev AD. Effect of protein kinase modulators on the induction of morphological differentiation of pheochromocytoma PC12 cells by nerve and fibroblast growth factors. Biotechnol Appl Biochem. 1990;12(1):20-7. Non-berry. [pmid: 2155622].
Rabin BM, ShukittHale B, Szprengiel A, Joseph JA. Effects of heavy particle irradiation and diet on amphetamine- and lithium chloride-induced taste avoidance learning in rats. Brain Res. 2002;953(12):31-6. Non-berry. [pmid: 12384235].
Ratty AK, Das NP. Effects of flavonoids on nonenzymatic lipid peroxidation: structure-activity relationship. Biochem Med Metab Biol. 1988;39(1):69-79. Non-berry chemical. [pmid: 3355718].
Ravaglia G, Forti P, Maioli F, Scali RC, Arnone G, Talerico T, Pantieri T, Nativio V, Mantovani V, Bianchin M. Common polymorphisms in methylenetetrahydrofolate reductase (MTHFR): relationships with plasma homocysteine concentrations and cognitive status in elderly northern italian subjects. Arch Gerontol Geriatr Suppl. 2004;(9):339–48. No outcome of interest
Ravaglia G, Forti P, Maioli F, Scali RC, Saccheitti L, Talerico T, Mantovani V, Bianchin M. Homocysteine and cognitive performance in healthy elderly subjects. Arch Gerontol Geriatr Suppl. 2005;(9):349–57. All normal cognition (correlation study)
Ravaglia G, Forti P, Maioli F, Zanardi V, Dalmonte E, Grossi G, Cucinotta D, Macini P, Caldarera M. Blood homocysteine and vitamin B levels are not associated with cognitive skills in healthy normally ageing subjects.[see comment]. J Nutr Health Aging. 2000;4(4):218-22. N<100 (B12 or Folate correlation). [pmid: 11115804].
Regland B, Abrahamsson L, Blennow K, Gottfries CG, Wallin A. Vitamin B12 in CSF: reduced CSF/serum B12 ratio in demented men. Acta Neurol Scand. 1992;85(4):276-81. N<100 (excluding vascular and other). [pmid: 1585799].
Regland B, Blennow K, Germgard T, KochSchmidt AC, Gottfries CG. The role of the polymorphic genes apolipoprotein E and methylene- tetrahydrofolate reductase in the development of dementia of the Alzheimer type. Dement Geriatr Cogn Disord. 1999;10(4):245-51. No outcome of interest. [pmid: 10364640].
Regland B, Gottfries CG, Oreland L. Vitamin B12-induced reduction of platelet monoamine oxidase activity in patients with dementia and pernicious anaemia. Eur Arch Psychiatry Clin Neurosci. 1991;240(45):288-91. No outcome of interest. [pmid: 1829005].
Richardson JS. Neuroprotective agents. Phys Med Rehabil Clin N Am. 1999;10(2):447-61. Review. [pmid: 10370940].
Riggs KM, Spiro A, Tucker K, Rush D. Relations of vitamin B-12, vitamin B-6, folate, and homocysteine to cognitive performance in the Normative Aging Study. Am J Clin Nutr. 1996. All normal cognition (correlation study)
Roberge AG. Differentiation in brain and liver DOPA/5HTP decarboxylase activity after L-DOPA administration with or without pyridoxine in cats. J Neurochem. 1977;28(3):479-85. No outcome of interest. [pmid: 300789].
Robertson DM, Manz HJ. Effect of thiamine deficiency on the competence of the blood-brain barrier to albumin labeled with fluorescent dyes. Am J Pathol. 1971;63(3):393-402. Immature rats. [pmid: 5581230]. [pmcid: 2047487].
Robertson DM, Wasan SM, Skinner DB. Ultrastructural features of early brain stem lesions of thiamine-deficient rats. Am J Pathol. 1968;52(5):1081-97. Immature rats. [pmid: 5646511]. [pmcid: 2013350].
Robins Wahlin TB, Wahlin A, Winblad B, Backman L. The influence of serum vitamin B12 and folate status on cognitive functioning in very old age. Biol Psychol. 2001;56(3):247-65. All normal cognition (correlation study). [pmid: 11399353].
Roos D, Willanger R. Various degrees of dementia in a selected group of gastrectomized patients with low serum B12. Acta Neurol Scand 55(5):363–76. 1977. N<100 (B12 or Folate correlation)
Roth A, Schaffner W, Hertel C. Phytoestrogen kaempferol (3,4′,5,7-tetrahydroxyflavone) protects PC12 and T47D cells from beta-amyloid-induced toxicity. J Neurosci Res. 1999;57(3):399-404. Non-berry chemical. [pmid: 10412031].
Sachdev P, Parslow R, Salonikas C, Lux O, Wen W, Kumar R, Naidoo D, Christensen H, Jorm A. Homocysteine and the brain in midadult life: evidence for an increased risk of leukoaraiosis in men. Arch Neurol. 2004;61(9):1369-76. No B vitamin results. [pmid: 15364682].
Sachdev PS, Valenzuela M, Wang XL, Looi JC, Brodaty H. Relationship between plasma homocysteine levels and brain atrophy in healthy elderly individuals. Neurology. 2002;58(10):1539-41. No B vitamin results. [pmid: 12034795].
Sagara Y, Vanhnasy J, Maher P. Induction of PC12 cell differentiation by flavonoids is dependent upon extracellular signal-regulated kinase activation. J Neurochem. 2004;90(5):1144-55. Non-berry chemical. [pmid: 15312169].
SamhanArias AK, MartinRomero FJ, GutierrezMerino C. Kaempferol blocks oxidative stress in cerebellar granule cells and reveals a key role for reactive oxygen species production at the plasma membrane in the commitment to apoptosis. Free Radic Biol Med. 2004;37(1):48-61. Non-berry chemical. [pmid: 15183194].
Saura CA, Tomita T, Davenport F, Harris CL, Iwatsubo T, Thinakaran G. Evidence that intramolecular associations between presenilin domains are obligatory for endoproteolytic processing. J Biol Chem. 1999;274(20):13818-23. No outcome of interest. [pmid: 10318786].
Scalabrino G, Tredici G, Buccellato FR, Manfridi A. Further evidence for the involvement of epidermal growth factor in the signaling pathway of vitamin B12 (cobalamin) in the rat central nervous system. J Neuropathol Exp Neurol. 2000;59(9):808-14. Not B vitamin study. [pmid: 11005261].
Scapagnini G, Butterfield DA, Colombrita C, Sultana R, Pascale A, Calabrese V. Ethyl ferulate, a lipophilic polyphenol, induces HO-1 and protects rat neurons against oxidative stress. Antioxid Redox Signal. 2004;6(5):811-8. Non-berry chemical. [pmid: 15345140].
Schaper CG, Ansink BJ, Ploem JE. Subacute combined degeneration of the spinal cord and the vitamin B12 metabolism, a clinical study. Clin Neurol Neurosurg. 1979;81(1):26-38. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 223794].
Schroecksnadel K, Leblhuber F, Frick B, Wirleitner B, Fuchs D. Association of hyperhomocysteinemia in Alzheimer disease with elevated neopterin levels. Alzheimer Dis Assoc Disord. 2004;18(3):129-33. N<100 (B12 or Folate correlation). [pmid: 15494618].
Schroeter H, Spencer JP, RiceEvans C, Williams RJ. Flavonoids protect neurons from oxidized low-density-lipoprotein-induced apoptosis involving c-Jun N-terminal kinase (JNK), c-Jun and caspase-3. Biochem J. 2001;358(Pt 3):547-57. Non-berry chemical. [pmid: 11535118]. [pmcid: 1222091].
Schroeter H, Williams RJ, Matin R, Iversen L, RiceEvans CA. Phenolic antioxidants attenuate neuronal cell death following uptake of oxidized low-density lipoprotein. Free Radic Biol Med. 2000;29(12):1222-33. Non-berry chemical. [pmid: 11118812].
Schurr A, Payne RS, Miller JJ, Tseng MT, Rigor BM. Blockade of lactate transport exacerbates delayed neuronal damage in a rat model of cerebral ischemia. Brain Res. 2001;895(12):268-72. Non-berry chemical. [pmid: 11259789].
Scott TM, Tucker KL, Bhadelia A, Benjamin B, Patz S, Bhadelia R, Liebson E, Price LL, Griffith J, Rosenberg I, Folstein MF. Homocysteine and B vitamins relate to brain volume and white-matter changes in geriatric patients with psychiatric disorders. Am J Geriatr Psychiatry. 2004;12(6):631-8. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 15545331].
Selley ML, Close DR, Stern SE. The effect of increased concentrations of homocysteine on the concentration of (E)-4-hydroxy-2-nonenal in the plasma and cerebrospinal fluid of patients with Alzheimer's disease.[see comment]. Neurobiol Aging. 2002;23(3):383-8. N<100 (B12 or Folate correlation). [pmid: 11959400].
Shea TB, Ashline D, Ortiz D, Milhalik S, Rogers E. The S-adenosyl homocysteine hydrolase inhibitor 3-deaza-adenosine prevents oxidative damage and cognitive impairment following folate and vitamin E deprivation in a murine model of age-related, oxidative stress-induced neurodegeneration. Neuromolecular Med. 2005;5(2):171-80. Combination B vitamin and other treatments.
Shea TB, Ortiz D, Rogers E. Differential susceptibity of transgenic mice lacking one or both apolipoprotein alleles to folate and vitamin E deprivation. J Alzheimers Dis. 2004;6(3):269-73. Combination B vitamin and other treatments. [pmid: 15201481].
Shea TB, Ortiz D. 17 beta-estradiol alleviates synergistic oxidative stress resulting from folate deprivation and amyloid-beta treatment. J Alzheimers Dis. 2003;5(4):323-7. No outcome of interest. [pmid: 14624028].
Sheu KF, Calingasan NY, Lindsay JG, Gibson GE. Immunochemical characterization of the deficiency of the alpha-ketoglutarate dehydrogenase complex in thiamine-deficient rat brain. J Neurochem. 1998;70(3):1143-50. B vitamin antagonist. [pmid: 9489735].
Shirai N, Suzuki H. Effect of dietary docosahexaenoic acid and catechins on maze behavior in mice. Ann Nutr Metab. 2004;48(1):51-8. Non-berry chemical. [pmid: 14646341].
Shorvon SD, Carney MW, Chanarin I, Reynolds EH. The neuropsychiatry of megaloblastic anaemia. Br Med J. 1980;281(6247):1036-8. N<100 (B12 or Folate correlation). [pmid: 6253016]. [pmcid: 1714413].
Shutenko Z, Henry Y, Pinard E, Seylaz J, Potier P, Berthet F, Girard P, Sercombe R. Influence of the antioxidant quercetin in vivo on the level of nitric oxide determined by electron paramagnetic resonance in rat brain during global ischemia and reperfusion. Biochem Pharmacol. 1999;57(2):199-208. Non-berry chemical. [pmid: 9890569].
Singh A, Naidu PS, Kulkarni SK. Quercetin potentiates L-Dopa reversal of drug-induced catalepsy in rats: possible COMT/MAO inhibition. Pharmacology. 2003;68(2):81-8. Non-berry chemical. [pmid: 12711835].
Singh A, Naidu PS, Kulkarni SK. Reversal of aging and chronic ethanol-induced cognitive dysfunction by quercetin a bioflavonoid. Free Radic Res. 2003;37(11):1245-52. Non-berry chemical. [pmid: 14703737].
Sjogren M, Wikkelso C, Ostling S, Wallin A, Blennow K. Biological correlates of clinical subgroups of Alzheimer's disease. Dement Geriatr Cogn Disord. 2002;14(4):191-7. No B vitamin results. [pmid: 12411761].
Skaper SD, Fabris M, Ferrari V, Dalle CM, Leon A. Quercetin protects cutaneous tissue-associated cell types including sensory neurons from oxidative stress induced by glutathione depletion: cooperative effects of ascorbic acid. Free Radic Biol Med. 1997;22(4):669-78. Non-berry chemical. [pmid: 9013129].
Slanina P, Frech W, Bernhardson A, Cedergren A, Mattsson P. Influence of dietary factors on aluminium absorption and retention in the brain and bone of rats. Acta Pharmacol Toxicol. 1985;56(4):331-6. No outcomes of interest.
Small BJ, Backman L. Predictors of longitudinal changes in memory, visuospatial, and verbal functioning in very old demented adults. Dement Geriatr Cogn Disord. 1998;9(5):258-66. No B vitamin results. [pmid: 9701677].
Small BJ, Viitanen M, Winblad B, Backman L. Cognitive changes in very old persons with dementia: the influence of demographic, psychometric, and biological variables. J Clin Exp Neuropsychol. 1997. N<100 (B12 or Folate correlation)
Smidt LJ, Cremin FM, Grivetti LE, Clifford AJ. Influence of thiamin supplementation on the health and general well-being of an elderly Irish population with marginal thiamin deficiency. J Gerontol. 1991;46(1):M16-22. No outcome of interest. [pmid: 1986037].
Sneath P, Chanarin I, Hodkinson HM, McPherson CK, Reynolds EH. Folate status in a geriatric population and its relation to dementia. Age Ageing. 1973. No outcome of interest
Sohn YT, Oh JH. Characterization of physicochemical properties of ferulic acid. Arch Pharm Res. 2003;26(12):1002-8. Non-berry chemical. [pmid: 14723331].
Soliman KF, Mazzio EA. In vitro attenuation of nitric oxide production in C6 astrocyte cell culture by various dietary compounds. Proc Soc Exp Biol Med. 1998;218(4):390-7. Non-berry. [pmid: 9714085].
Soliman KF. Polyphenols, flavonoids, food constituents and oils attenuate neurodegenerative process. Ethn Dis. 2001;11(1):165-6. Review. [pmid: 11289242].
Sommer BR, Wolkowitz OM. RBC folic acid levels and cognitive performance in elderly patients: a preliminary report. Biol Psychiatry. 1998;24(3):352-4. N<100 (B12 or Folate correlation).
Spencer JP, RiceEvans C, Williams RJ. Modulation of pro-survival Akt/protein kinase B and ERK1/2 signaling cascades by quercetin and its in vivo metabolites underlie their action on neuronal viability. J Biol Chem. 2003;278(37):34783-93. Non-berry chemical. [pmid: 12826665].
Spencer JP, Schroeter H, Crossthwaithe AJ, Kuhnle G, Williams RJ, RiceEvans C. Contrasting influences of glucuronidation and O-methylation of epicatechin on hydrogen peroxide-induced cell death in neurons and fibroblasts. Free Radic Biol Med. 2001;31(9):1139-46. Non-berry chemical. [pmid: 11677047].
Spindler AA, Renvall MA. Nutritional status and psychometric test scores in cognitively impaired elders. Ann N Y Acad Sci. 1989;561:167-77. N<100 (B12 or Folate correlation). [pmid: 2735676].
Steiner H, Revesz T, Neumann M, Romig H, Grim MG, Pesold B, Kretzschmar HA, Hardy J, Holton JL, Baumeister R, Houlden H, Haass C. A pathogenic presenilin-1 deletion causes abberrant Abeta 42 production in the absence of congophilic amyloid plaques. J Biol Chem. 2001;276(10):7233-9. Not B vitamin study. [pmid: 11084029].
Suarez J, Herrera MD, Marhuenda E, PerezGuerrero C. Effect of hesperidin and neohesperidin dihydrochalcone on central nervous system. Fitoterapia. 1996. Non-berry chemical
Summanen J, Vuorela P, Rauha JP, Tammela P, Marjamaki K, Pasternack M, Tornquist K, Vuorela H. Effects of simple aromatic compounds and flavonoids on Ca2+ fluxes in rat pituitary GH(4)C(1) cells. Eur J Pharmacol. 2001;414(23):125-33. Non-berry chemical. [pmid: 11239912].
Sweeney MI, Kalt W, MacKinnon SL, Ashby J, GottschallPass KT. Feeding rats diets enriched in lowbush blueberries for six weeks decreases ischemia-induced brain damage. Nutr Neurosci. 2002;5(6):427-31. No outcomes of interest. [pmid: 12509072].
Tabet N, Mantle D, Walker Z, Orrell M. Vitamins, trace elements, and antioxidant status in dementia disorders. Int Psychogeriatr. 2001;13(3):265-75. Cross-sectional intake study of patients with dementia. [pmid: 11768374].
Takahashi K, Fukuda M, Nakamura H. Subacute combined degeneration of the spinal cord with normal absorption of vitamin B12. Yonago Acta Med. 1969;13(2):145-51. Case report. [pmid: 5371862].
Tall JM, Seeram NP, Zhao C, Nair MG, Meyer RA, Raja SN. Tart cherry anthocyanins suppress inflammation-induced pain behavior in rat. Behav Brain Res. 2004;153(1):181-8. Non-berry. [pmid: 15219719].
Tarabal O, Caldero J, Llado J, Oppenheim RW, Esquerda JE. Long-lasting aberrant tubulovesicular membrane inclusions accumulate in developing motoneurons after a sublethal excitotoxic insult: a possible model for neuronal pathology in neurodegenerative disease. J Neurosci. 2001;21(20):8072-81. No outcome of interest. [pmid: 11588180].
Tarnopolsky MA, Beal MF. Potential for creatine and other therapies targeting cellular energy dysfunction in neurological disorders. Ann Neurol. 2001;49(5):561-74. Review. [pmid: 11357946].
Teunissen CE, Blom AH, Van Boxtel MP, Bosma H, de Bruijn C, Jolles J, Wauters BA, Steinbusch HW, de Vente J. Homocysteine: a marker for cognitive performance? A longitudinal follow-up study. J Nutr Health Aging. 2005;7(3):153-9. All normal cognition (correlation study).
Thomas DE, ChungAOn KO, Dickerson JW, Tidmarsh SF, Shaw DM. Tryptophan and nutritional status of patients with senile dementia. Psychol Med. 1986;16(2):297-305. N<50 (Food frequency questionnaire). [pmid: 3726005].
Toda S. Inhibitory effects of phenylpropanoid metabolites on copper-induced protein oxidative modification of mice brain homogenate, in vitro. Biol Trace Elem Res. 2002;85(2):183-8. Non-berry chemical. [pmid: 11899025].
Todd KG, Butterworth RF. Evaluation of the role of NMDA-mediated excitotoxicity in the selective neuronal loss in experimental Wernicke encephalopathy. Exp Neurol. 1998;149(1):130-8. B vitamin antagonist. [pmid: 9454622].
Torres I, Smith WT, Oxnard C. Degeneration of the peripheral and central nervous system in vitamin-B12-deficient monkeys. Experientia. 1969;25(3):273-5. No outcome of interest. [pmid: 4976460].
Torronen R, Maatta K. Bioactive substances and health benefits of strawberries. Acta Hortic. 2002. Review
Tsai TH, Lee CH, Yeh PH. Effect of P-glycoprotein modulators on the pharmacokinetics of camptothecin using microdialysis. Br J Pharmacol. 2001;134(6):1245-52. Non-berry chemical. [pmid: 11704644]. [pmcid: 1573054].
Tucker DM, Penland JG, Sandstead HH, Milne DB, Heck DG, Klevay LM. Nutrition status and brain function in aging. Am J Clin Nutr. 1990;52(1):93-102. No outcome of interest. [pmid: 2360555].
Turchan J, Pocernich CB, Gairola C, Chauhan A, Schifitto G, Butterfield DA, Buch S, Narayan O, Sinai A, Geiger J, Berger JR, Elford H, Nath A. Oxidative stress in HIV demented patients and protection ex vivo with novel antioxidants. Neurology. 2003;60(2):307-14. Non-berry chemical. [pmid: 12552050].
van Duyn MAS, Pivonka E. Overview of the health benefits of fruit and vegetable consumption for the dietetics professional: selected literature. J Am Diet Assoc. 2000. Review
van Meeteren ME, Hendriks JJ, Dijkstra CD, van Tol EA. Dietary compounds prevent oxidative damage and nitric oxide production by cells involved in demyelinating disease. Biochem Pharmacol. 2004;67(5):967-75. Non-berry chemical. [pmid: 15104250].
Van Wymelbeke V, Guedon A, Maniere D, Manckoundia P, Pfitzenmeyer P. A 6-month follow-up of nutritional status in institutionalized patients with Alzheimer's disease. J Nutr Health Aging. 2004. No outcome of interest
Ventura P, Panini R, Verlato C, Scarpetta G, Salvioli G. Hyperhomocysteinemia and related factors in 600 hospitalized elderly subjects. Metabolism. 2001;50(12):1466-71. No B vitamin results. [pmid: 11735095].
Vermeulen EGJ, Stehouwer CDA, Valk J, Knaap Mvd, Berg Mvd, Twisk JWR, Prevoo W, Rauwerda JA. Effect of homocysteine-lowering treatment with folic acid plus vitamin B6 on cerebrovascular atherosclerosis and white matter abnormalities as determined by MRA and MRI: a placebo-controlled, randomized trial. Eur J Clin Invest. 2005. No outcome of interest
Vietri M, Vaglini F, Cantini R, Pacifici GM. Quercetin inhibits the sulfation of r(-)-apomorphine in human brain. Int J Clin Pharmacol Ther. 2003;41(1):30-5. Non-berry chemical. [pmid: 12564743].
Volk C, Kempski B, Kempski OS. Inhibition of lactate export by quercetin acidifies rat glial cells in vitro. Neurosci Lett. 1997;223(2):121-4. Non-berry chemical. [pmid: 9089688].
Wahlin A, Hill RD, Winblad B, Backman L. Effects of serum vitamin B12 and folate status on episodic memory performance in very old age: a population-based study. Psychol Aging. 1996;11(3):487-96. All normal cognition (correlation study). [pmid: 8893317].
Wang B, Foo L, Polya GM. Differential inhibition of eukaryote protein kinases by condensed tannins. Phytochemistry. 1996. No outcomes of interest
Wang CN, Chi CW, Lin YL, Chen CF, Shiao YJ. The neuroprotective effects of phytoestrogens on amyloid beta protein-induced toxicity are mediated by abrogating the activation of caspase cascade in rat cortical neurons. J Biol Chem. 2001;276(7):5287-95. 2001 Non-berry chemical. [pmid: 11083861].
Wang H, Joseph JA. Structure-activity relationships of quercetin in antagonizing hydrogen peroxide-induced calcium dysregulation in PC12 cells. Free Radic Biol Med. 1999;27(56):683-94. Non-berry chemical. [pmid: 10490289].
Watkins SE, Thomas DE, Clifford M, Tidmarsh SF, Sweeney AE, AhSing E, Dickerson JW, Cowie VA, Shaw DM. Plasma amino acids in patients with senile dementia and in subjects with Down's syndrome at an age vulnerable to Alzheimer changes. J Ment Defic Res. 1989;33(Pt 2):159-66. No B vitamin results. [pmid: 2524595].
Weeks BS, Wilson PJ, Heffernan CC, Gorra VA, White LE, Ahmad A. Laminin stimulates protein tyrosine dephosphorylation in PC12 cells. Biochem Biophys Res Commun. 1999;262(3):713-9. Non-berry chemical. [pmid: 10471391].
Wenk GL, McGannGramling K, HaussWegrzyniak B, Ronchetti D, Maucci R, Rosi S, Gasparini L, Ongini E. Attenuation of chronic neuroinflammation by a nitric oxide-releasing derivative of the antioxidant ferulic acid. J Neurochem. 2004;89(2):484-93. Non-berry chemical. [pmid: 15056291].
Whalley LJ, Staff RT, Murray AD, Duthie SJ, Collins AR, Lemmon HA, Starr JM, Deary IJ. Plasma vitamin C, cholesterol and homocysteine are associated with grey matter volume determined by MRI in non-demented old people. Neurosci Lett. 2003;341(3):173-6. No outcome of interest. [pmid: 12697276].
Widner B, Leblhuber F, Frick B, Laich A, ArtnerDworzak E, Fuchs D. Moderate hyperhomocysteinaemia and immune activation in Parkinson's disease. J Neural Transm. 2002;109(12):1445-52. No outcome of interest. [pmid: 12486485].
Willis L, Bickford P, Zaman V, Moore A, Granholm AC. Blueberry extract enhances survival of intraocular hippocampal transplants. Cell Transplant. 2005. No outcomes of interest
Woo J. Relationships among diet, physical activity and other lifestyle factors and debilitating diseases in the elderly. Eur J Clin Nutr. 2000;54(Suppl 3):S143-7. Review. [pmid: 11041086].
Wu BY, Yu AC. Quercetin inhibits c-fos, heat shock protein, and glial fibrillary acidic protein expression in injured astrocytes. J Neurosci Res. 2000;62(5):730-6. Non-berry chemical. [pmid: 11104512].
Xu YF, Zhang YJ, Zhang AH, Zhang Q, Wu T, Wang JZ. Attenuation of okadaic acid-induced hyperphosphorylation of cytoskeletal proteins by heat preconditioning and its possible underlying mechanisms. Cell Stress & Chaperones. 2004;9(3):304-12. Non-berry chemical. [pmid: 15544168]. [pmcid: 1065289].
Yagyu K, Kitagawa K, Wu B, Zhang NY, Irie T, Hattori N, Inagaki C. Protective effects of estradiol against amyloid beta protein-induced inhibition of neuronal Cl(-)-ATPase activity. Neuropharmacology. 2002;43(8):1297-304. Non-berry chemical. [pmid: 12527479].
Yan JJ, Cho JY, Kim HS, Kim KL, Jung JS, Huh SO, Suh HW, Kim YH, Song DK. Protection against beta-amyloid peptide toxicity in vivo with long-term administration of ferulic acid. Br J Pharmacol. 2001;133(1):89-96. Non-berry chemical. [pmid: 11325798]. [pmcid: 1572763].
Yang XJ, Kow LM, Funabashi T, Mobbs CV. Hypothalamic glucose sensor: similarities to and differences from pancreatic beta-cell mechanisms. Diabetes. 1999;48(9):1763-72. Non-berry chemical. [pmid: 10480606].
Youdim KA, Martin A, Joseph JA. Incorporation of the elderberry anthocyanins by endothelial cells increases protection against oxidative stress. Free Radic Biol Med. 2000;29(1):51-60. No outcomes of interest. [pmid: 10962205].
Youdim KA, McDonald J, Kalt W, Joseph JA. Potential role of dietary flavonoids in reducing microvascular endothelium vulnerability to oxidative and inflammatory insults (small star, filled). J Nutr. Biochem. 2002;13(5):282-8. No outcomes of interest.
Youdim KA, ShukittHale B, Joseph JA. Flavonoids and the brain: interactions at the blood-brain barrier and their physiological effects on the central nervous system. Free Radic Biol Med. 2004;37(11):1683-93. Review. [pmid: 15528027].
Youdim KA, ShukittHale B, MacKinnon S, Kalt W, Joseph JA. Polyphenolics enhance red blood cell resistance to oxidative stress: in vitro and in vivo. Biochim Biophys Acta. 2000;1523(1):117-22. No outcomes of interest. [pmid: 11099865].
Yukawa M, Naka H, Murata Y, Katayama S, Kohriyama T, Mimori Y, Nakamura S. Folic acid-responsive neurological diseases in Japan. J Nutr Sci Vitaminol. 2001;47(3):181-7. Ineligible population (and/or no sub-analysis of age-related neurocognitive disease). [pmid: 11575572].
ZapataTorres G, Opazo F, Salgado C, Munoz JP, Krautwurst H, Mascayano C, SepulvedaBoza S, Maccioni RB, Cassels BK. Effects of natural flavones and flavonols on the kinase activity of Cdk5. J Nat Prod. 2004;67(3):416-20. Non-berry chemical. [pmid: 15043421].
Zelaya FO, Rose SE, Nixon PF, Wholohan BT, Bower AJ, Zimitat C, Schoutrop J, Doddrell DM. MRI demonstration of impairment of the blood-CSF barrier by glucose administration to the thiamin-deficient rat brain. Magn Reson Imaging. 1995;13(4):555-61. Mixed B vitamin with other treatments (glucose). [pmid: 7674851].
Zensho H, Nishida A, Shimizu M, Uchitomi Y, Yamawaki S. Heat shock protein 72 restores cyclic AMP accumulation after heat shock in N18TG2 cells. Brain Res. 1998;790(12):278-83. Non-berry chemical. [pmid: 9593940].
Zhao Y, Gao Z, Li H, Xu H. Hemin/nitrite/H(2)O(2) induces brain homogenate oxidation and nitration: effects of some flavonoids. Biochim Biophys Acta. 2004;1675(13):105-12. Non-berry chemical. [pmid: 15535973].
Zheng J, Ramirez VD. Inhibition of mitochondrial proton F0F1-ATPase/ATP synthase by polyphenolic phytochemicals. Br J Pharmacol. 2000;130(5):1115-23. Non-berry chemical. [pmid: 10882397]. [pmcid: 1572158].
Zhou A, Matsumoto T, Farver O, Thorn NA. Uptake of ascorbic acid by freshly isolated cells and secretory granules from the intermediate lobe of ox hypophyses. Acta Physiol Scand. 1990;138(2):229-34. Non-berry chemical. [pmid: 2316381].
Zhu M, Phillipson JD, Greengrass PM, Bowery NE, Cai Y. Plant polyphenols: biologically active compounds or non-selective binders to protein? Phytochemistry. 1997. Non-berry chemical
Zhu M, Rajamani S, Kaylor J, Han S, Zhou F, Fink AL. The flavonoid baicalein inhibits fibrillation of alpha-synuclein and disaggregates existing fibrils. J Biol Chem. 2004;279(26):26846-57. Non-berry chemical. [pmid: 15096521].
Zielasek J, Muller B, Hartung HP. Inhibition of cytokine-inducible nitric oxide synthase in rat microglia and murine macrophages by methyl-2,5-dihydroxycinnamate. Neurochem Int. 1996;29(1):83-7. Non-berry chemical. [pmid: 8808792].