# Appendix C. Evidence Tables

## B Vitamin Evidence Tables - Animal / In Vitro Studies

Thiamine

Author, Year | Jolicoeur, 1979 (2 publications)
Central hypothesis/Stated Purposes of the study | To devise a standard battery of tests capable of quantitatively characterizing ataxia in the laboratory rats
Hypothesis diagram | Thiamine deficiency → ataxia indicated by lower performances on a standard battery of tests
Experimental diets or reagents | Thiamine-free diet (ICN Life Sciences, Nutritional Biochemical)
Control diets or reagents | Standard rat chow (Purina Rat Chow) in daily rations equivalent to the amounts consumed by the thiamine deficient animals
Study characteristics | Country: Canada
| Funding source: Conseil de la Recherche en Sante du Quebec and the Medical Research Concil of Canada
Gap in Knowledge | Known: Chronic deficiency of vitamin B1 results in pervasive metabolic and biochemical alterations in the nervous system. Thiamine deficiency induces a peripheral neuropathy of the “dying back” type which involves both sensory and motor nerve fibers. When rats are chronically fed a thiamine-free diet, a variety of disturbances such as anorexia, poloerection, tremors, kypokinesia and ataxia develop at about 30–40 days from the start of the diet.
| Unknown: Standard method and procedure for detecting and measuring ataxia in experimental animals has not been developed.
Experimental model | Male Sprague Dawley rats, 275–350 g in weight
Study design | Parallel experiment-controlled study
Final sample size | Control: 6 Thiamine-free: 6
Duration | 44 days
Measurements / Endpoints / Outcomes of interest | Locomotor activity: spontaneous locomotor activity was measured for 3 minutes by means of a photocell activity apparatus
| Catalepsy: Intensity of catalepsy was determined by placing the animals' front paws on a horizontal bar (1 cm in width) suspended 10 cm above the table. Time spent in the position, up to a maximum of 60 seconds, was recorded.
| Rigidity: the rat was suspended by its front paws grasping a metal rod (0.5 cm diameter) which was held by the experimenter about 50 cm above the table. The time the animal remained on the bar (maximum 60 sec) was recorded.
| Landing foot spread: After staining the handpaws with ink, the animal was held horizontally 30 cm above a table covered with absorbent paper. The rat was dropped and the distance between the prints of each hindlimb was measure.
| Gait analysis: After staining the hindfeet with ink, the animal was walked through an enclosed 90 cm long corridor with a paper covered floor. When 2 consecutive strides were obtained, the stride width, length and angle between consecutive steps on contralateral sides were calculated.
| Reflexive responses: The presence of the righting and corneal reflexes as well as of a normal reaction to tail pinch was verified.
Other outcomes reported
Results | Statistical analysis indicated that only transient and sporadic effects were produced during initial phase (days 7, 14, 21, 27, and 33) of the thiamine deficiency (TD). On day 21, TD animals displayed significantly less locomotor activity than pair fed controls. A significant decrease in locomotion was also found on day 33 but not on day 27. The gait angles and widths of deficient animals were respectively decreased and increased on day 27 while length of stride was unchanged. On day 33 stride length was significantly decreased in TD rats but the other 2 gait parameters remained unaffected.
| During days 35 to 44, all TD animals lost the righting reflex, displayed impaired weight shift responses, and eventually died. These effects were not seen in pair fed controls. No significant group differences group differences were found for activity, catalepsy, rigidity, and landing foot spread. Also, aside from the righting reflex and weight shift responses, no other reflexes were affected in TD animals. Finally, gait analysis revealed that in TD rats the angle and length of strides were significantly smaller than those of pair fed controls.
Authors' Conclusions | Thiamine deficiency did not yield similar neurobehavioral effects as acrylamide- or 3-acetyl pyridine-induced ataxia. Only the righting reflex and weight shift response were similarly affected by both TD and pyrithiamin treatment. However, all 3 components of gait were disturbed in both TD animals.
Quality | B
Limitations / Comments | Purina rata chow was not an appropriate control diet. The composition of diets prepared using crude materials are known to fluctuate from a batch-to-batch. Thus, it is difficult to obtain reproducible data.

Thiamine

Author, Year | Zimitat, 1990
Central hypothesis/Stated Purposes of Study | To differentiate between the contributions of alcohol consumption and thiamine deficiency to the pathogenesis of Wernicke's encephalopathy. Evaluate acute neurological disease by histology.
Hypothesis diagram | EtOH +/- Thiamine deficiency → Wernicke's encephalopathy
Experimental diets or reagents | 1 Thiamine fortified: purified solid diet, thiamine 50 mg/Kg, water to drink; 2 Thiamine fortified/EtOH: purified solid diet, thiamine 50 mg/Kg, 15% EtOH in water (ad lib); 3 Thiamine deficient: purified solid diet, thiamine 0 mg/Kg (implied), water to drink; 4 Thiamine deficient /EtOH: purified solid diet, thiamine 0 mg/Kg (implied), 15% EtOH in water (ad lib)
Control diets or reagents | Cereal based solid diet, thiamine 8 mg/Kg, water to drink
Study characteristics | Country: Australia
| Funding source:Government
Gap in Knowledge | Known: Wernicke's encephalopathy associated with both thiamine deficiency and EtOH abuse
| Unknown: The independent effects of thiamine deficiency and EtOH on neuropathology
Experimental model | Wistar rats, 9 wk, female (6/cage, light/dark cycle 12 hr each, 23° C, mesh floors and feeders washed 3x/wk to prevent coprophagy and fecal contamination)
Study design | Divided into 5 diet groups. Evaluated 3x/wk for food and fluid intake, clinical signs of neurological disease. Brains harvested either when displayed signs of opisthotonus and were moribund (thiamine deficient) or at age 44 wk
Final sample size | Clinical evaluation/Brain histopathology:
| Thiamine fortified: 12/6; Thiamine fortified/EtOH: 12/6; Thiamine deficient: 18/5; Thiamine deficient/EtOH: 18/6; Control: 12/5
Duration | 35 wk
Measurements / Endpoints / Outcomes of interest | Ataxia; Opisthotonus; Moribund state or death;
| Brain pathology
Other outcomes reported | Diet intake, weight gain, brain weight and volume, biochemistry
Results | Control and thiamine fortified rats showed no signs of clinical disease. Starting at 5–10 wk, all thiamine deficient rats eventually developed ataxia, opisthotonus, and moribund state.
| Control and thiamine fortified rats: 1 in each group had brain hemorrhage, rest had no abnormality on histopathology.
| Thiamine deficient rats: 4/11 had no abnormality, 7 had hemorrhages, of which 3 had necrosis (1 mild, 1 severe) and 2 had vacuolation. Pathologies seen primarily in the medial vestibular nucleus
Authors' Conclusions | Symptoms and pathology due to thiamine deficiency (not EtOH). (Symptoms and pathology due to thiamine deficiency exacerbated and hastened by EtOH.)
Quality | B
Limitations / Comments | ? of value for age-related neurodegenerative disease
| Primary purpose of study is to investigate Wernicke's encephalopathy. However, comparison of EtOH to water diets not included here.

Thiamine

Author, Year | Terasawa, 1999
Central hypothesis/Stated Purposes of Study | To evaluate the influence of thiamine on learning ability of rats.
Hypothesis diagram | Thiamine → role in nervous function → learning ability
Experimental diets or reagents | Modified AIN-76 with thiamine HCl 30 mg per 100 g
Control diets or reagents | Modified AIN-76 with thiamine HCl 60 mg per 100 g (normal intake)
Study characteristics | Country: Japan
| Funding source: Government
Gap in Knowledge | Known: Thiamine plays a role in nervous function, possibly as part of nerve Na channel
| Unknown: Thiamine effect on learning
Experimental model | Wistar rats, weighing either 260–300 g
| Electrodes placed in periaqueductal gray matter. Trained to press lever to stop electrical stimulation (which causes escape behavior)
Study design | While on normal diet taught to stop electrical stimulation by pressing a lever positioned in an L maze. One training session / day. Then divided into 2 groups, one continuing normal diet, other given low thiamine diet.
Final sample size | 5 in each group
Duration | ~42 days after start of low thiamine diet (until rats stopped responding to stimulus)
Measurements / Endpoints / Outcomes of interest | Response time: Time from start stimulation until start action (escape behavior)
| Running time: Time from start action until presses lever
| Task completion time: Response time + Running time
Other outcomes reported | none
Results | Normal thiamine rats: Response time, Running time, and Task completion time all remained over time.
| Low thiamine rats:
| Response time: For about 3 weeks, remained stable, then progressively slowed until stopped responding
| Running time: Similar pattern to response time; running time began to slow after response time slowed; observed that rats became more likely to get to lever but not press it.
Authors' Conclusions | Response and running times slowed in thiamine deficient rats. Response time became longer first, then running time.
Quality | C
Limitations / Comments | Poor description of experiment. It appears that rats in normal thiamine group evaluated over whole time period (phase 1 before dividing into groups and phase 2 after division) while rats in low thiamine group analyzed only in phase 2. Appears that this is an experiment testing loss of learning or loss of motor function, since learning done prior to deficiency and may not be testing cognitive function.

Experiment comparing blood thiamine levels in rats without electrode implantation, with electrode but no training, and with electrode with training is not included here.

Thiamine

Author, Year | Ciccia, 2000
Central hypothesis/Stated Purposes of the study | Ethanol and thiamine deficiency (TD) act synergistically, producing more severe clinical neurological disturbances and cognitive and memory impairments than either TD or chronic ethanol alone
Hypothesis diagram | Ethanol + TD → more severe clinical neurological disturbances and cognitive and memory impairments than either TD or chronic ethanol alone [For the purpose of this report, we only focus on the comparison of TD vs. control diet]
Experimental diets or reagents | Animals were treated as control animals except during the 3 episodes of TD, each of which lasted approximately 4.5 weeks.
| Beginning at weeks 10, 18, and 26 of treatment, the animals were exposed to a bout of TD. During each bout of TD, the animals were fed ad libitum thiamine-deficient chow (Harlan Tekland, Madison, WI) and received intraperitoneal injections of saline 3 times weekly. Each bout of TD was ended by administration of a single dose of thiamine (100 mg/kg body weight, intraperitoneally) and restoration of regular chow.
Control diets or reagents | All animals received ad libitum vitamin-fortified chow and water and were given thiamine (1 mg/kg intraperitoneally) 3 times per week (Monday, Wednesday, Friday)
Study characteristics | Country: US
| Funding source: No data
Gap in Knowledge | Known: The prolonged and heavy consumption of ethanol has been associated with a wide range of cognitive impairments. TD can induce white matter and more subtle gray matter damage without damaging mamillary bodies.
| Unknown: Cognitive impairments in chronic alcoholics may be caused by a synergistic interaction between ethanol and TD.
Experimental model | Male Sprague Dawley rats approximately 2 months of age at the start of the study
Study design | Paralleled experiment-controlled study
Final sample size | Control: 14 TD:12
Duration | 8 months (including 3 times TD periods; each TD period lasted about 4.5 weeks)
Measurements / Endpoints / Outcomes of interest | Behavioral testing: spontaneous activity, spontaneous alternation, nonmatching-to-position (NMTP), delayed NMTP, reversal learning of matching-to-position (MTP), delayed MTP, and reversal learning of NMTP
| Clinical observations
Other outcomes reported | Body weights
Results | Behavioral testing:
| At different stages of behavioral testing, 5 control rats and 2 TD rats either died of unknown causes or developed tumors and were killed. Thus, group sizes reported on each behavioral task are different.
| There was no significant differences in the response time of spontaneous activity between TD and control rats.
| For spontaneous alternation, the TD group (n=13) made more perseverative choices than the CT group (n=13) but the difference did not reach statistical significance. No significance differences were observed in the percentage of alternations or omissions between the groups.
| For NMTP acquisition trials, the average performance of all groups was well above chance on the first session and reached 90% accuracy on session 5. Analysis of the group performance across session 1 through 5 revealed a significant effect of session but no significant treatment effect. All of the TD (n=12) and control (n=13) animals reached criterion level of performance.
| For delayed NMTP trials, there was no difference in the performances on delayed NMTP trials between TD (n=12) and control (n-=13) animals.
| For first reversal learning MTP, despite extensive training, 1 TD rat failed to reach criterion and all control animals attained criterion within the maximum 30 sessions of training. Analyses of the performance of animals that did learn the task did not show any significant difference between TD and control animals.
| For delayed MTP trials, the accuracy of the TD group was near chance at the 120 sec delay, whereas the control group accuracy was close to 70%. TD animals (n=10) performed significantly lower than controls on 120 sec delayed trials (p<0.0001)
| For second reversal learning, all of the control and TD animals successfully relearned the NMTP task within the allotted number of sessions. There was no significant difference in accuracy over the initial 16 sessions between the groups.
| For task failure, no control animals failed to meet criterion for each behavioral task while TD animals had an overall failure rate of 9%.
| Clinical observations:
| During the course of each bout of thiamine deficiency, animals in TD group developed several clinical signs, including weight loss, slowed activity, ataxia, opisthotonos, and impaired righting reflex.
| There were no clinical signs of neurological or behavioral disturbances in any group when fed the thiamine-fortified chow.
Authors' Conclusions | About 3 months after cessation of TD treatment, the TD rats had significantly impaired on the long (120 sec) delayed trials of MTP trials. The observation suggest that repeated episodes of TD treatment produced impairment of working memory. However, because we did not provide pair-fed controls for TD treatment, it is possible that working memory deficits may have been caused by caloric reductions rather than the specific effects of TD toxicity.
| Overall results of the present study demonstrate that TD produced significant learning impairments on the conditional position discrimination tasks. However the percentage of TD animals that demonstrated learning deficits was relatively small (8%).
Quality | B
Limitations / Comments | There are no pair-fed controls for TD treatment, it is possible that working memory deficits may have been caused by caloric reductions (TD rats had significantly less weight at the end) rather than the specific effects of TD toxicity.

B6

Author, Year | Tunnicliff et al., 1972
Central hypothesis/Stated Purposes of the study | Increased pyridoxal-5′-phosphate (PLP) concentration might lead to increased stability of some behaviors, this might be observed as decreased in variance in behavioral variability in animals of uniform genetic constitution.
Hypothesis diagram | Dietary B6 → ↑ PLP → ↑ stability of some behaviors
Experimental diets or reagents | Group 1: average 3 μg of pyridoxine HCL a day
| Group 2: average 15 μg of pyridoxine HCL a day
| Group 3: average 150 μg of pyridoxine HCL a day
| The amount of B6 was estimated based on each animal drank approximately 5ml of water and ate about 5 g of food each day
Control diets or reagents | None
Study characteristics | Country: US
| Funding source: Office of Education, Department of Health, Education and Welfare; National Institute of Neurological Diseases and Stroke, NIH
Gap in Knowledge | Known: Vitamin B6 is the precursor of PLP. There is good evidence that pyridoxine in the diet is eventually converted to PLP in the brian. There is accumulating evidence that dietary vitamin B6 levels can influence behavior.
| Unknown: Decreasing levels of PLP may result first in its selective unavailability as a cofactor for some processes of neurotransmitter metabolism. It might, therefore, be expected that levels of performance should be selectively affected for certain behaviors under specific dietary conditions.
Experimental model | C57BL/6J and DBA/2J inbred strains of mice (9 weeks old). These 3 inbred populations of mice have been shown to differ on certain behavioral measures, including open-field activity.
Study design | Tested over 5 successive days for 5 min a day in the open-field for locomotor activity, then over a further 5 days for active escape learning, and finally they were tested for passive avoidance learning
Final sample size | 50 male animals in each strain were used for the experiments.
| Group 1: 15 Group2: 20 Group 3: 15
Duration | On diet for 4 weeks
Measurements / Endpoints / Outcomes of interest | 1 locomotor activity; 2 active escape learning; 3 passive avoidance learning
| Both the mean scores and the variances were computed for each of the 3 behavioral tests
Other outcomes reported | Glutamic acid decarboxylase in brain
Results | Of the 3 tests, only locomotor activity in the open-field is affected by the dietary pyridoxine.
| For locomotor activity, no significant difference in mean scores, but variances in all 3 dietary groups were significantly different from each other:
| Group 1 compared to group 2 (p<0.01)
| Group 2 compared to group 3 (p<0.001)
| Group 1 compared to group 3 (p<0.01)
| Variance was greatest in group 2 (15 μg of pyridoxine HCL) and least in group 3 (150 μg of pyridoxine HCL)
Authors' Conclusions | A specified diet has an effect on behavioral variability. Since both the inbred strains of mice were equally effected by the vitamin B6 diets, authors conclude that the response is not the result of some peculiar genetic defect, but is one that involves biochemical systems fundamental to the organism.
Quality | B
Limitations / Comments | No explanation why groups were unbalanced. No control animal
| Unable to explain a decrease in variances in those animals on the low pyridoxine diet.

B6

Author, Year | Driskell, 1973
Central hypothesis/Stated Purposes of the study | To assess the value of behavioral measurements, brain pyridoxal phosphate, nucleic acid and protein contents and erythrocyte alanine aminotransferase activities as criteria in establishing the vitamin B6 requirement of weanling and sexually mature male rats
Hypothesis diagram | Inadequate vitamin B6 intake → impairments of behavioral measurements
Experimental diets or reagents | The basal diet supplemented with 15, 30, 45, 60, 75, or 90 μg pyridoxine per 15 g diet
Control diets or reagents | A Basal diet containing: (in %) vitamin-free casein, 15, sucrose, 29, cornstarch and vitamin mix, 34.88, cellulose, 2; Jones-Foster (15) salt mixture, 4, hydrogenated fat, 10; L-methionine, 0.08, L-cystine, 0.04, and corn oil with vitamins A, D, and E, 5.
Study characteristics | Country: US
| Funding source: No data
Gap in Knowledge | Known: Vitamin B6 is needed in prenatal growth particularly by the central nervous system. The brain completes most of its growth during the prenatal period; its maturation is completed early in life.
| Unknown:
Experimental model | Virgin mature female rats weighing approximately 220 g
Study design | Randomized controlled trial
Final sample size | Control: 6
| B6 15, 30, 45, 60, 75, or 90 μg/15 g diet: 6, 6, 6, 6, 6, 6 respectively
Duration | 3 weeks
Measurements / Endpoints / Outcomes of interest | Activity and curiosity: Animals were tested in a runway measuring 85 cm long and 23 cm wide. Phtoelectric cells located at the midpoint counted the number of times the animal traversed the runway (activity). A small metal object attached to a metal disk 3.8 cm in diameter was electrically isolated from the floor such that simultaneous contact of the object and floor registered a count (curiosity). Animals were tested during 15-minute intervals on 14 consecutive days.
| Learning: T maze with water as a reinforcer. Measures obtained were correctness of response choice and latency (time from beginning of a trial to choice by the animal).
| Emotionality: Fecal boli were counted for each animal during all testing sessions.
Other outcomes reported | Brain composition, including pyridoxal kinase activity, pyridoxal phosphate content, RNA and DNA analysis, and protein analysis)
| Erythrocyte alanine aminotransferase activity
Results | For sexually mature rats only, curiosity responses were significantly lower in the groups receiving 15 (p<0.01) and 30 (p<0.05) μg of vitamin B6 daily than in animals receiving higher levels. There is no difference in the curiosity between animals receiving 45, 60, 75, and 90 μg of vitamin B6 daily.
| For sexually mature rats only, the 15 and 30 μg of vitamin B6 daily groups had significantly lower activity scores (p<0.01) than animals on the higher pyridoxine levels. There is no difference in activity scores between animals receiving 45, 60, 75, and 90 μg of vitamin B6 daily.
| There were no significant differences in maze performance among the dietary groups in sexually mature rats.
Authors' Conclusions | The data obtained in this study indicated that the rat required an intake of 30 to 45 μg of vitamin B6 daily in order to exhibit a stabilized level of activity and curiosity.
| A simple learning task, as exemplified by the T maze data obtained in this study, reflected no significant difference between the dietary groups.
Quality | A
Limitations / Comments | For the purpose of our report, we only look at the outcomes for sexually mature rats

B12

Author, Year | Masuda, 1998
Central hypothesis/Stated Purposes of the study | The effects of egg PC combined with vitamin B12 on memory of nucleus basalis magnocellularis (NBM) lesioned rats in the Morris water maze task, and on choline or ACh concentrations in the brain of NBM lesioned rats
Hypothesis diagram | PC + vitamin B12 → ↑choline or Ach in the brain of NBM lesioned rats → ↑water maze performances
Experimental diets or reagents | PC group: control diet plus 10 g/kg of egg yolk PC (PL-100LE, 92% PC; Q/P/ Corp., Tokyo)
| Vit B12 group: control diet plus 1.0 mg/kg of vitamin B12 (Sigma)
| PC+Vit B12 group: control diet plus 10 g/kg of egg yolk PC and 1.0 mg/kg of vitamin B12
| Egg PC and Vitamin B12 which were dissolved in water were administered orally using intragastric tube for 18 days after surgery (for inducing NBM lesions)
Control diets or reagents | 20% casein diet, containing protein (casein: 200 g/kg), carbohydrate (corn starch and sucrose: 675 g/kg), fat (corn oil: 50 g/kg), fiber (cellulose powder: 20 g/kg), mineral mix (40 g/kg), vitamin mix (10 g/kg), DL-methionine (3 g/kg) and choline (2 g/kg)
Study characteristics | Country: Japan
| Funding source: No data
Gap in Knowledge | Known: Acetylcholine (Ach) is an essential neurotransmitter which plays a role in learning and memory. In AD, the most remarkable change of neurotrasmitters is the decrease of Ach, especially in the cerebral cortex. Several studies have shown the increase of brain choline and Ach contents in rodents. The problem is that learning and memory were not evaluated in these studies.
| Unknown: The effects of phosphatidylcholine (PC) combined with vitamin B12 on memory of rats.
Experimental model | Male Wistar rats weighing 250–300 g with NBM lesion (one of the animal model which mimics some of the cholinergic hypofunction and memory loss associated with Alzheimer's disease)
Study design | Paralleled experiment-controlled trial
Final sample size | SHAM-Ctrl: 10 NBM-Ctrl: 10 NBM-B12: 10 NBM-PC: 10 NBM-B12+PC: 10
Duration | 10–18 days, depending on experiments
Measurements / Endpoints / Outcomes of interest | Spontaneous movements were measured by Animex counter (AUTOMEX II, Columbus Instruments) for 10 min on 3 consecutive days after surgery 10–12
| Morris water maze task: on day 14 after surgery, water maze task was carried out. All animals were trained for 3 consecutive days (during days 14, 15, 16 after surgery)
| Spatial probe (Retention): the next day after acquisition test (on day 17 after surgery), were removed the platform and allowed the rats to swim for 60 sec. The time spent in the west quadrant where the platform had been located during training was measured.
Other outcomes reported | Brian choline and Ach concentrations
Results | There was no significant difference in spontaneous movements of rats between groups.
| Worris water maze:
| - Acquisition:; The unlesioned SHAM-ctrl group had significantly shorter latencies than the NBM-ctrl group for 3, 4 and 5 blocks (p<0.05, NK). NBM-ctrl group remained learning deficit and required 20–30 sec to find the platform, even; Latencies of acquisition in NBM-12 group was not statistically different from that of the NBM-ctrl group.; - Spatial probe (Retention):; In NBM lesioned rats, the time spent in the platform-quadrant was significantly shorter than that in the sham control rats (p<0.01, NK); Times of the NBM-B-12 group was not statistically different from that of the NBM-ctrl group.
Authors' Conclusions | Low dose (1 mg/kg) of vitamin B12 alone did not recover the depletion of choline and Ach concentrations in the frontal cortex and did not improve memory of NBM lesioned rats. If shortage of choline in the frontal cortex markedly occurred by NBM lesioning, activation of choline acetyltransferase by vitamin B12 may not be useful for ACh synthesis.
Quality | A
Limitations / Comments | For the purpose of this review, only results from the comparisons of Vit B12 to control groups are considered.
| Vitamin B12 is usually included 0.05 mg/kg diet (equivalent to about 0.001 mg/kg) in the standard stock diet for rats.
| Vitamin B12 was dissolved in water were administered orally using intragastric tube, and the duration of intervention was relatively short.

Folate

Author, year | Duan, 2002
Central hypothesis/Stated Purposes of the study | By increasing Homocysteine (Hcy) levels, folate deficiency endangers dopaminergic neurons thereby increasing the risk of Parkinson's disease
Hypothesis diagram | Folate deficiency → ↑Hcy → dysfunction and death in dopaminergic neurons → PD
Experimental diets or reagents | Folate deficient diet (FD diet): diet lacked folate, but was otherwise identical to the control diet.
Control diets or reagents | Standard mouse diet (Dyets, Inc.; diet #518754) which contained 2 mg folate/kg of food.
Study characteristics | Country: US
| Funding source: ND
Gap in Knowledge | Known: PD is characterized by dysfunction and degeneration of dopaminergic neurons in the substantia nigra resulting in progressive akinesia, tremor and rigidity. Recent findings suggest the Hcy levels are increased in PD patients.
| Unknown: Whether or not folate deficiency and/or elevated Hcy levels play a critical role in the pathogenesis of PD.
Experimental model | The toxin 1-methyl-4-phenyl-1,2,3,6-tetrahydropyridine (MPTP) induces PD-like pathology and behavioral symptoms model in 2-month-old male C57B1/6 mice weighing 21–23 g
Study design | After 3 months dietary treatments, both experiment and control animals (5-month old mice) received either 2 i.p. injections of 20 mg MPTP/kg body weight, separated by 4 hours, a regiment that resulted in no detectable pathology or symptomology, or saline injections. Behavior testing for motor function was assessed 1 week later. 24-hr later, mice were killed and brains were rapidly removed; the striata were removed and stored at -80 °C until used for measurements of monoamines and metabolites.
Final sample size | FD diet - MPTP 10 FD diet - Saline 10
| Ctrl diet - MPTP 10 Ctrl diet - Saline 10
Duration | 3 months
Measurements / Endpoints / Outcomes of interest | Motor performance was assessed with a rotary rod apparatus. Both the total time spent on the rotating rod and the total number of falls for each mouse were recorded
| Number of dopaminergic neurons in substantia nigra: counted TH immunoreactive neurons in the substantia nigra (SN) of each mouse
Other outcomes reported | Plasma Hcy levles
| Levels of tyrosine hydroxylase (TH; an enzyme required for dopamine synthesis) in the striatum
Results | Folate deficiency alone did not impair performance on rotarod tests. There was no significant difference in the time on the rotarod or in the number of falls between animals on folate deficient diet and those on control diet. Folate deficiency alone did not affect striatal TH levels nor numbers of TH-positive neurons in the SN.
| FD diet + MPTP injection → marked decrease in TH levels in the striatum; marked 50–60% loss of dopaminergic neurons in the SN (p<0.01) → significant decrease in time on the rotarod (p<0.01); significant increase in the numbers of falls per 5 min (p<0.01)
Authors' Conclusions | In contrast to mice on the control diet that were resistant to the subtoxic dose of MPTP, mice that had been maintained on the folate-deficient diet exhibited profound motor dysfunction as indicated by a decrease in the time period they could maintain themselves on the rotarod and by an increased numbers of falls.
Quality | A
Limitations / Comments

Folate

Author, Year | Kim, 2002
Central hypothesis/Stated Purposes of Study | To investigate the effects of folate deprivation on plasma homocysteine, and its cerebrovascular and neurotoxic effects, we induced hyperhomocystinemia in rats by folate deprivation and examined the morphological alterations in cerebral microvasculature by electron microscopy
Hypothesis diagram
Experimental diets or reagents | Folate deficient diet (folate-D): Diet #31; Samtaco without added folate
Control diets or reagents | Folate-supplemented diet (folate-S): Diet #31; Samtaco adding 0.004 g folate/kg diet
Study characteristics | Country: Korea
| Funding source: Government
Gap in Knowledge | Known:
| Unknown:
Experimental model | Male Sprague-Dawley rats (6-mo-old) (Samtaco, Osan, Korea
Study design | Paralleled experimental-control trial, blinded analyses
Final sample size | 8 per group
Duration | 8 weeks
Measurements / Endpoints / Outcomes of interest | Electron microscopic findings for cerebrocortical microvascular wall in brain cross sections
Other outcomes reported | Weight gain, food intake, plasma homocysteine levels
Results | Rats fed folate-S diet (control) showed a normal cerebral capillary wall with a relatively smooth luminal surface and a regular thin layer of basement membrane around the endothelium, surrounging a pericyte.
| A degenerative appearance of the cerebrocortical microvascular wall was shown in rats fed folate-D diet. High amplitude mitochondrial swelling (m) with disintegration of mitochondrial cristae and dissolution of cytoplasmic organelles in the endothelial cell cytoplasm are exhibited. Abnormal electron-lucent structures indicating perivascular amorphous fibrosis are observed within the basement membrane and in the perivascular area. Locally and irregularly thickened basement membrane is also observed in cerebral microvessels of folate-deficient rats. Frequent perivascular detachment was observed in relatively large cerebral microvessels. Characteristic degenerative pericytes including mitochondrial and cytoplasmic swollen profiles are also shown.
Authors' Conclusions
Quality | A
Limitations / Comments | The folate-S diet is considered “standard diet” or control diet.

Folate

Author, Year | Kruman, 2002
Central hypothesis/Stated Purposes of the study | Folate deficiency and Hcy sensitize neurons to Aβ-induced death
Hypothesis diagram | Folate deficiency and Hcy → increase Aβ-induced death of hippocampal cells → Increase risk of AD
Experimental diets or reagents | Diet lacked folate and contained 4.5 gm/kg D,L-homocysteine (Dyetes Incorporated; diet 518806)
Control diets or reagents | Standard mouse diet that contained defined choline and folate and lacked D,L-homocysteine (Dyets, Incorporated, Bethlehem, PA; diet 518754)
Study characteristics | Country: US
| Funding source: No data
Gap in Knowledge | Known: In AD the death of neurons in brain regions critical for learning and memory is believed to result from increased production and accumulation of insoluble forms of amyloid β-peptide (Aβ), which may endanger and kill neurons by inducing OS and disrupting cellular ion homeostasis. DNA damage has been documented in association with neuronal degeneration in brain tissues of AD patients. Folate deficiency and homocysteine, which can impair DNA repair in non-neuronal cells.
| Unknown: Whether folate deficiency and homocysteine can promote neurons to Aβ-induced death
Experimental model | 7-month-old amyloid precursor protein (APP) mutant mice. These mice develop age-dependent deposition of Aβ in their brains, which is first evident in the hippocampus and cerebral cortex beginning after 10 months of age.
Study design | 7-month-old APP mutant mice and littermate non-transgenic control mice were maintained on either a control diet or a folic acid-deficient diet. After 3 months on the diets, blood was taken and brains were removed.
Final sample size | No data
Duration | 3 months
Measurements / Endpoints / Outcomes of interest | ELISA and immuohistochemical analysis of Aβ production or deposition: ELISA for soluble and plaque-associated Aβ1–42 and Aβ1–40 was performed
| Quantification of hippocampal pyramidal neurons: Nissl-possitive undamaged neurons were counted in the entire extent of the pyramidal cell layer, including regions CA1 and CA3 (CA2 was included in counts for CA3)
Other outcomes reported | Homocysteine levels
Results | Levels of Aβ1–40 and Aβ1–42 were below the limit of detection in non-transgenic mice (data not shown), while the levels were ~4 and 2 nmol/gm wet brain weight, respectively in APP mutant mice that had been maintained on either the control or folate-deficient diets, with no significant differences in levels of either Aβ species between mice on control or folate deficient diets. The ratio Aβ1–42/ Aβ1–40 also was not changed by the folate-deficient diet.
| Examination of brain sections immunostained with an antibody against Aβ revealed no evidence of extracellular amyloid deposition in APP mutant mice that had been maintained on either diet.
| The analyses in regions CA3 of hippocampus revealed a highly significant 20% loss of neurons in APP mutant mice on the flate-deficient diet compared with mutant mice on the control diet (p<0.0001); however, there was no differences in the volume densities of neurons in region CA1 between the groups.
Authors' Conclusions | Folate deficiency renders hippocampal CA3 neurons in APP mutant mice vulnerable to death by a mechanism that dose not involve increased Aβ production or deposition.
Quality | B
Limitations / Comments | The in vitro experiments in this article were excluded due to mixed folate and methionine deficient media used.
| No data on the numbers of animals per group

AD gene

Author, Year | Shea, 2002 [2964]
Central hypothesis/Stated Purposes of the study | Folate compensates for the diminished oxidative buffering capacity of brains of apoE deficient mice.
Hypothesis diagram | Beta-amyloid -> generalized oxidative damage -> neurodegeneration
| ApoE deficiency ?-> free Fe levels -> ↑reactive oxygen species
| Dietary folate deficiency -> ↑Hcy -> CNS oxidative damage and potentiates beta-amyloid and glutamate neurotoxicity-> neurodegeneration
Experimental diets or reagents | Vitamin-free, basal diet (AIN-76) Fe challenge with Fe (ferric citrate 8 g/kg)
| [Vitamin E supplement (alpha-tocopherol, 50 IU/kg) not considered experimental diet here]
| 1 - Folate, + Vit E, - Fe; 2 - Folate, - Vit E, - Fe; 3 - Folate, + Vit E, + Fe; 4 - Folate, - Vit E, + Fe
Control diets or reagents | Vitamin-free, basal diet (AIN-76) supplemented with folic acid (4 mg/kg total diet wet weight)
| 1 + Folate, + Vit E, - Fe; 2 + Folate, - Vit E, - Fe; 3 + Folate, + Vit E, + Fe; 4 + Folate, - Vit E, + Fe
Study characteristics | Country: US
| Funding source: ND
Gap in Knowledge | Known: Folate deficiency leads to oxidative damage and neurodegeneration
| Unknown: The effect of folate on preventing oxidative damage in normal and ApoE deficient mice
Experimental model | 1 ApoE^tmlUne^ homozygous knockout mice on a C57B1/6J background, 10–14 mo old; 2 Normal C57B1/6J mice, 10–14 mo old
Study design | Mice fed experimental or control diets for 1 month, after which total CNS tissue was harvested, homogenized, normalized according to total protein and aliquots of unfractionated homogenates were analyzed for TBARs
Final sample size | 12 mice per experiment
Duration | 1 month
Measurements / Endpoints / Outcomes of interest | TBARs, “an end-point index of oxidative damage”
Other outcomes reported
Results | 1 CNS of normal mice did not contain increased TBARS following Fe challenge in the presence or absence of folate.; 2 ApoE knockout mice without folate had significantly increased TBARS when challenged with Fe.; 3 ApoE knockout mice with folate did not have increased TBARs when challenged with Fe.
Authors' Conclusions | The genetic deficiency of a complete absence of ApoE can be alleviated with folate repletion. This may provide a partial explanation as to why certain ApoE alleles are associated with increased prevalence and earlier onset of AD, yet do not exhibit 100% penetrance.
Quality | A
Limitations / Comments | TBARs are a rough estimate only of oxidative damage. In this experiment they derived from a combination of lipid, protein and DNA oxidative damage.
| TBARs measured from whole CNS, not just key brain areas related to AD, such as hippocampus and cortex.
| Experiment does not distinguish between cerebrovascular and neuronal oxidative damage.
| No “clinical” outcomes.

ApoE, apolipoprotein E, CNS, central nervous system TBAR, thiobarbituric acid-reactive substances.

AD gene

Author, Year | Shea, 2002 [2966]
Central hypothesis/Stated Purposes of the study | Test hypothesis that deficiencies in ApoE function are associated with increased oxidative stress in CNS.
| Compare responses of transgenic mice lacking ApoE with those of normal mice to dietary oxidative stress induced by folate dprivation (and by inclusion of excess iron within their diet).
Hypothesis diagram | ApoE deficiency ->↑ susceptibility to oxidative damage
| Dietary folate deficiency -> ↑Oxidative stress -> CNS oxidative damage
Experimental diets or reagents | Vitamin-free, basal diet (AIN-76) supplemented with folic acid (4 mg/kg total diet wet weight)
| Fe challenge with Fe (ferric citrate 8 g/kg)
| 1 + Folate, - Fe; 2 + Folate, + Fe
Control diets or reagents | Vitamin-free, basal diet (AIN-76)
| 1 - Folate, - Fe; 2 - Folate, + Fe
Study characteristics | Country: US
| Funding source: ND
Gap in Knowledge | Known: Folate deficiency leads to oxidative damage and neurodegeneration
| Unknown: The effect of folate on preventing oxidative damage in normal and ApoE deficient mice
Experimental model | 1 ApoE^tmlUne^ homozygous knockout mice on a C57B1/6J background; 2 Normal C57B1/6J mice
Study design | Mice fed experimental or control diets for 1 month, after which total CNS tissue was harvested, homogenized, and prepared for measurements
Final sample size | 3–4 mice per diet per experiment
Duration | 1 month
Measurements / Endpoints / Outcomes of interest | 1 TBARs; 2 Total antioxidant activity in CNS homogenates in a cell-free assay
Other outcomes reported | Glutathione
Results | 1 ApoE-deficient mice had significantly increased TBARs when challenged with Fe in the absence of folate, in contrast to ApoE-deficient mice challenged with Fe in the presence of folate and to normal mice, regardless of folate or Fe status.; 2 Antioxidant capacity lower in ApoE-deficient mice receiving Fe in the absence of folate compared to same mice receiving folate or compared to normal mice, regardless of folate status.
Authors' Conclusions | In the setting of ApoE deficiency, mice are incapable of overcoming oxidative stress of Fe without folate.
| The combined influence of Fe challenge and folate deprivation depletes the antioxidant capacity of ApoE-deficient mice.
Quality | A
Limitations / Comments | TBARs are a rough estimate only of oxidative damage. In vitro antioxidant capacity might not reflect in vivo oxidative capacity.
| TBARs measured from whole CNS, not just key brain areas related to AD, such as hippocampus and cortex.
| No “clinical” outcomes.

ApoE, apolipoprotein E

TBAR, thiobarbituric acid-reactive substances.

CNS, central nervous system

AD gene

Author, Year | Shea, 2003 [2968]
Central hypothesis/Stated Purposes of the study | Deficiencies in ApoE function are associated with increased oxidative stress in CNS. This was carried out by comparing the responses of transgenic mice lacking ApoE with those of normal mice of the identical genetic background to dietary oxidative stress induced by folate deprivation and by inclusion of excess iron within their diet.
Hypothesis diagram
Experimental diets or reagents | Vitamin-free, basal diet (AIN-76)
| Fe challenge with Fe (ferric citrate 8 g/kg)
| 1 + Folate, - Fe; 2 + Folate, + Fe
Control diets or reagents | Vitamin-free, basal diet (AIN-76) supplemented with folic acid (4 mg/kg total diet wet weight)
| 1 - Folate, - Fe; 2 - Folate, + Fe
Study characteristics | Country: US
| Funding source: ND
Gap in Knowledge | Known:
| Unknown:
Experimental model | Normal C57B1/6J mice and ApoE homozygous knockout mice on a C57B1/6J background were maintained for one month on a basal diet with and without folic acid; and with or without iron. Homogenates of CNS were measured.
Study design | Mice fed experimental or control diets for 1 month, after which total CNS tissue was harvested, homogenized, and prepared for measurements
Final sample size | Samples were derived from 3 to 4 normal and 3 to 4 ApoE -/- mice for each dietary condition, from 3 to 4 separate experiments (total n ≥ 12 for each diet for all 3 experiments)
Duration
Measurements / Endpoints / Outcomes of interest | thiobarbituric acid-reactive substances (TBARs) as an index of endpoint oxidative damage
| Trolox equivalent antioxidant capacity
Other outcomes reported | glutathione level in CNS
Results | CNS of ApoE deficient mice demonstrated an approximate 20% increase in glutathione levels compared to normal mice.
| Individually, deprivation of folate and dietary iron each increased glutathione levels in CNS of both normal and ApoE-deficient mice.
| In combination, folate deprivation with dietary iron further increased glutathione levels in both normal and ApoE-deficient mice.
| However, CNS of ApoE-deficient mice displayed a markedly greater increase than did CNS of normal mice under all condtions.
| ApoE deficient mice displayed increased TBARs when challenged with dietary iron in the absence of folate (p<0.05).
| In the absence of any dietary challenge, CNS of ApoE -/- mice exhibited a significantly increased oxidative buffering capacity vs. that of normal mice (p<0.05).
| ApoE deficient mice receiving iron in the absence of folate displayed less CNS antioxidant capacity than under any other condition for these mice.
Authors' Conclusions | 1 These findings demonstrate that ApoE deficient mice are less capable of buffering oxidative challenge than are normal mice.; 2 These findings also suggest that the increased levels of glutathione observed in CNS of ApoE deficientl mice following dietary challenge with iron and folate deficiency were incapable of compensating for the lack of ApoE function.; 3 The lack of ApoE activity fostered an increase in one or more endogenous antioxidants.; 4 Folate deprivation fostered an additonal increase in antioxidant in normal CNS.; 5 Endogenous antioxidants were upregulated in CNS of both strains of mice in response to oxidative stress.; 6 The combined influence of iron challenge and folate deprivation depleted the antioxidant capcity of ApoE deficient mice.; 7 These data support the hypothesis that ApoE deficiency is associated with increased oxidative stress.
Quality | A
Limitations / Comments

AD gene

Author, Year | Fuso, 2005
Central hypothesis/Stated Purposes of the study | The nutritional deficits could lead to Hcy/SAM metabolism alteration (hyper-homocysteinemia) with the con sequent decrease of SAM levels.
| Alterations in SAM/Hcy cycle (producing Hcy accumulation) are responsible for decreased SAM (S-adenosylmethionine) levels and, in turn, for reduced DNA methylation.
Hypothesis diagram | Folate and B12 deficient → Hcy cannot transform to SAM → ↑ Hcy and ↓ SAM → reduced DNA methylation → modulation gene expression (such as amyloid precursor protein (APP) processing and ß-amyloid (Aß) production through the regulation of Presenilin1 (PS1) expression)
Experimental diets or reagents | Deprive medium (DDM): It was prepared substracting folate and vitamin B12 from the preparation of F14 medium and used with 1% fetal calf serum plus 10μM retinoic acid. The residual folate and vitamin B12 concentrations were 60 and 2.3 pg/ml, respectively.
| These vitamin amounts derived only from the fetal calf serum (FCS) added to the medium.
Control diets or reagents | Differentiation medium (DM): F14 medium with 1% fetal calf serum plus 10 μM retinoic acid
Study characteristics | Country: Italy
| Funding Source: MIUR grants (Ateneo and FIRB 2003)
Gap in Knowledge | Known: Elevated Hcy plasma level is a serious risk factor for the onset of AD. Moreover SAM levels decrease in AD patients and, generally, with aging. The great relevance of Aß production in AD is largely documented and accepted, as well as the importance of reducing this protein in the therapy.
| Unknown: Correlation between the SAM/Hcy cycle, DNA methylation and AD
Experimental model | 2 different neuroblastoma cell lines: SK-N-SH and SK-N-BE. Since the 2 lines gave similar results in all the experiment performed, we decided to show only the results relative to SK-N-BE cell line.
Study design | In vitro
Final sample size | 4 or 5 depending on experiments
Duration | N/A
Measurements / Endpoints / Outcomes of interest | PS1 and PS2 expression
| APP expression
Other outcomes reported | Apoptosis, SAM production, γ- and ß-secretases (BACE) production
Results | Gene expression, compared DM to DDM media:
| There was no significant difference in APP expression between the 2 groups both at 48 and 96 hours (n=4).
| PS1 expression was similar in DM while DDM induced high increase in PS1 expression (n=4, p<0.05).
| PS2 expression seems to be independent from the different experimental conditions, but with a little higher variability respect to APP.
| Protein expression, compared DM to DDM media:
| The 110-kDa APP isoform increased in DM and was more abundant after 144 hours in all the experimental conditions; nevertheless, there was no significant differences between DM and DDM cells (except for a decrease in DDM after 144 h, p<0.05) (n=5).
| PS1 protein was synthesized at similar levels in DM while DDM induce an increase in PS1 synthesis (n=5, p<0.05).
| PS2 synthesis seems to be independent from the experimental conditions.
Authors' Conclusions | Complete and deprived medium as well as FCS were preliminarily analyzed in order to verify that folate and vitamin B12 content was really low. We think that such a partial vitamin deprivation from the medium, instead of a total depletion, is more representative for a nutritional deficit. The HPLC analysis also allowed us to demonstrate that the intracellular SAM levels of cells grown in deprived medium were lower respect to the complete medium; this findings confirmed that Hcy metabolism alteration due to folate and vitamin B12 deprivation really caused the reduction of SAM levels in the cells.
| We demonstrated that PS1 can be induced by folate and vitamin B12 deprivation. The other genes involved in APP processing and APP itself seemed to be independent on medium deprivation.
Quality | A
Limitations / Comments | For the purpose of our review, the best comparison in this study is DDM vs. DM since the only differences in the contents of the media are the amount of folate and B12. Although growth medium (GM) is the control group in the original study, we should not compare DDM to GM because there is no retinoic acid (or vitamin A) in GM. Furthermore, the results or comparisons regarding the effects of additional SAM in the media are not of interest. Since the authors' primary purposes were not to examine the effects of folate and B12 on the gene expression, the conclusions of the original study focused on the effect of the additional SAM to the media on the gene expression.
| All measurements were performed in duplicate.

Blood-brain barrier or cerebrovascular endothelial function

Author, Year | Warnock, 1968
Central hypothesis/Stated Purposes of Study | Using labeling patterns of glutamate to study pyruvate metabolism of normal and thiamine deficient rats.
Hypothesis diagram | Pyruvate metabolism (to glutamic acid) that occurs in the liver or the brain result in different radiolabeling patterns of glutamic acid. Therefore, differences in glucose and pyruvate transport across the blood-brain barrier (BBB) can be measured in different conditions.
Gap in Knowledge | Known: As above. Pyruvate does not directly enter the brain of adult animals.
| Unknown: BBB transport in thiamine deficiency
Experimental diets or reagents | Thiamine deficient diet
Control diets or reagents | Thiamine adequate diet
Study characteristics | Country: US
| Funding source: Government
Experimental model | Male rats, Sprague-Dawley, initial weights of 50–65 g.
Study design | Parallel experiment-controlled trial
Final sample size | Thiamine deficient: 15
| Normal diet: 10
Duration | nd. “At first signs of polyneuritis.”
Measurements / Endpoints / Outcomes of interest | Brain glutamic acid radiolabelling 10 minutes after injection with Na Pyruvate-2-^14^C and decapitation. (If pyruvate is metabolized in the liver, brain glutamic acid would be labeled on carbon 4. If metabolized in the brain, glutamic acid would be labeled mainly on carbon 5.)
Other outcomes reported | Evaluation of rats given thiamine anti-metabolite oxythiamine.
Results | Pyruvate-2-^14^C entered the brain directly in adult thiamine deficient animals.
Authors' Conclusions | Selective transport across BBB was not functioning in a normal fashion.
Quality | B
Limitations / Comments | Duration of thiamine deficiency not stated, although sufficient to cause symptoms.

Blood-brain barrier or cerebrovascular endothelial function

Author, Year | Robertson, 1971
Central hypothesis/Stated Purposes of Study | To test the hypothesis that the blood brain barrier (BBB) remains intact with respect to plasma proteins in the early edematous lesion associated with thiamine deficiency, but becomes permeable to protein in the necrotic stage.
Hypothesis diagram
Gap in Knowledge | Known: Early stages of experimental thiamine deficiency causes intracellular edema in brainstem, without morphologic evidence of parenchymal or vascular necrosis.
| Unknown: Whether early changes are due to a defect of transport of plasma proteins across the BBB directly related to the deficiency.
Experimental diets or reagents | Synthetic thiamine-free diet (Nutritional Biochemical Corp) ad lib
Control diets or reagents | Same diet with thiamine HCl 40 μg/100 g body weight i.p. daily
Study characteristics | From day 28–46, bovine albumin conjugated with fluorescein isothiocyanate (FLA) or complexed with Evans blue (EBA) was administered IV. Animals were killed 30 minutes later. Brainstem and cerebellum were analyzed as transverse frozen sections.
| Brains were evaluated for both histology (degree of spongy edema, presence of congestion, hemorrhages, tissue necrosis and neuronal loss). Rats were then categorized into:
| Group A: Slight edema (n=10)
| Group B: More marked spongy reticulation, frequently accompanied by vascular congestion (n=14)
| Group C: Hemorrhages, tissue degradation and neuronal fallout. (n=22)
Experimental model | Immature female rats, Long Evans strain or Wistar Furth strain
Study design | Parallel, controlled study.
Final sample size | 56 analyzed
Duration | 28–46 days
Measurements / Endpoints / Outcomes of interest | Presence or absence of extravascular fluorescence in relation to the severity of lesion (n=46)
Other outcomes reported | Presence or absence of FLA or EBA in neural parenchyma (n=10)
Results | In control animals, specific fluorescence of the neuropil - that is, tissues beyond the vascular confines, was never seen.
| Extravascular fluorescence was present in 1/24 rat brains from Groups A+B (n=24).
| Extravascular fluorescence was present in 12/22 rat brains from Group C (n=22).
| P<0.001 for difference.
Authors' Conclusions | BBB is intact with respect to albumin in the early lesions of thiamin deficiency. Thus intracellular edema associated with early deficiency results from a defect in cell membrane transport rather than a vascular leak of the inflammatory type across BBB.
Quality | B
Limitations / Comments | Initially included 134 rats. Controls were selected in every fifth animal. Rats that died spontaneously (n=51), had perfusion failures (n=5), or had technical failures (n=22) were not evaluated. No breakdown number for animals that were not evaluated per group.

Blood-brain barrier or cerebrovascular endothelial function

Author, Year | Manz, 1972
Central hypothesis/Stated Purposes of Study | To follow up on earlier experiment reported in Robertson, 1971.
| To further define the nature and sequence of permeability changes of the BBB, using horseradish peroxidase.
Hypothesis diagram
Gap in Knowledge | Known: Early stages of experimental thiamine deficiency causes intracellular edema in brainstem, without morphologic evidence of parenchymal or vascular necrosis. These changes are not related to disrupted albumin transport across the BBB.
| Unknown: Other possible transport defects in BBB
Experimental diets or reagents | Synthetic thiamine-free diet (Nutritional Biochemical Corp) ad lib
Control diets or reagents | Same diet with thiamine HCl 40 μg/100 g body weight i.p. daily
Study characteristics | From day 30–45 of thiamine deficiency, horseradish peroxidase was administered IV. 1–6 hours later fixation was carried out with glutaraldehyde and animals were killed. Brainstem was fixed and prepared.
| Brains were evaluated both histology (edema, hemorrhage, necrosis) and under both light and electron microscopy for peroxidase granules. Rats were then categorized into:
| Group A: edema only (n=7)
| Group B: hemorrhage and necrosis. (n=30)
Experimental model | Immature female rats, Wistar Furth strain
Study design | Parallel, controlled study.
Final sample size | 49 analyzed (37 treated, 12 controls)
Duration | 30–45 days
Measurements / Endpoints / Outcomes of interest | Parenchymatous infiltration with horseradish peroxidase (HRP)
Other outcomes reported
Results | Under light microscopy 12 control rats and the 7 Group A rats had “qualitatively and quantitatively” the same pattern of peroxidase granules in phagocytes.
| Among the 30 Group B rats, 21 had a diffuse parenchymatous infiltration of the vestibular area, generally extensive; un unreported number had numerous large plump phagocytic cells within the vestibular area; 9 had linear deposits of reaction product along the course of vessels.
| 0/7 Group A rats had parenchymatous infiltration, 21/30 Group B rats did; P<0.001
| Under electron microscopy, control rats and Group A rats were devoid of peroxidase in the vascular basement membrane and the neural parenchyma.
| In Group B rats, the interendothelial junctional complexes were morphologically intact; reaction product was deposited in the contraluminal side basement membrane zone of intercellular gaps.
Authors' Conclusions | Confirms timing of BBB competence from Robertson 1971 study.
| BBB damage seen in later stages corresponds to damage seen from cold-injury edema and other models of cerebral edema.
| Leakage appears to be predominantly through the mechanism of pinocytosis (introduction of fluids into a cell by invagination of the cell membrane, followed by formation of vesicles within the cells), not disruption of interendothelial junctions.
| This may be due to the fact that thiamine is a necessary cofactor for several enzymes required for active transport across cell membranes.
Quality | A
Limitations / Comments | Initially included 99 rats. Rats that died spontaneously (n=21) or presenting technical difficulties (n=29) were not evaluated.

Blood-brain barrier or cerebrovascular endothelial function

Author, Year | Lee, 2004
Central hypothesis/Stated Purposes of Study | To clarify the effects of hyperhomocysteinemia on cerebral endothelial function and elucidate possible mechanisms of homocystine-induced vascular and neuronal toxicity.
Hypothesis diagram
Experimental diets or reagents | HF diet: AIN93M diet modified to contain folic acid and homocystine (Hcy): 0.3% Hcy and 0.008 g/kg folate
Control diets or reagents | H diet: AIN93M diet modified to contain 0.3% Hcy
Study characteristics | Country: Korea
| Funding source: Government
Gap in Knowledge | Known: Folate supplementation has proven to be effective in treating hyperhomocystinemia and endothelial dysfunction
| Unknown: The cerebrovascular effects of homocystine and folate supplementation are poorly understood
Experimental model | Male Sprague-Dawley rats (8 weeks old) (Samtaco, Osan, Korea)
Study design | Paralleled experimental-control trial
Final sample size
Duration | 2 weeks
Measurements / Endpoints / Outcomes of interest | Cerebral expression level of two markers for endothelial dysfunction: the glucose transporter protein (GLUT-1) and vascular cell adhesion molecule (VCAM-1)
| Endothelial nitric oxide synthase (eNOS): Samples of the brains were analyzed by Western blotting technique
Other outcomes reported | Plasma Hcy, vitamin B12 and folic acid
| Weight gain, food intake, food efficiency ratio
Results | When the rats with induced hyperhomocysteinemia received 2 weeks of dietary folate supplementaion with homocystine (group HF), the level of brain eNOS protein expression increased by 43.5±5.4% (p=0.04) compared to the 4 week homocystine diet (group (H group). The increase is in good agreement with the 27.4±2.7% (p=0.04) increase in the GLUT-1 level and the 42.9±4.9% (p=0.04) decrease in VCAM-1 level.
| Note: No significant difference in weight gain, food intake or food efficiency ratio between animals on HF and those on H diets.
Authors' Conclusions | This study shows that hyperhomocysteinemia induces endothelial dysfunction, characterized by reduced eNOS activity with concomitant changes in the VCAM-1 and GLUT content in the rat brain. In addition, these effects were significantly ameliorated by dietary supplementation with folate. To our knowledge, this is the first morphological study to demonstrate the beneficial effects of dietary folate on hyperhomocysteinemia-induced cerebral endothelial dysfunction in vivo.
| However, in the course of this study, an unexpected result was observed in the cerebral content of the VCAM-1 in the homocystine-fed animals (group H) - this was reduced rather than increase. The cause of this unexpected result for VCAM-1 is currently under investigation.
Quality | A
Limitations / Comments | Rats in folate diet group were fed a diet with Hcy for 2 weeks before changed to folate-supplmented diet. The original control rats were fed a diet without folate or Hcy for 2 weeks and then continued for another 2 weeks. For the purpose of this review, this comparison is not appropriate.

Blood-brain barrier or cerebrovascular endothelial function

Author, Year | Lee, 2005
Central hypothesis/Stated Purposes of Study | To evaluate the effects of 8 weeks of dietary folate supplementation on cerebral vascular damage induced by hyperhomosysteinemia in vivo, in particular investigating the structural features of the cerebral vasculature by electron microscopy.
Hypothesis diagram
Experimental diets or reagents | HF diet: AIN93M diet modified to contain folic acid and homocystine (Hcy): 0.3% Hcy and 0.008 g/kg folate
Control diets or reagents | H diet: AIN93M diet modified to contain 0.3% Hcy
Study characteristics | Country: Korea
| Funding source: Government
Gap in Knowledge | Known: Folate supplementation has proven to be effective in treating hyperhomocystinemia and endothelial dysfunction
| Unknown: The cerebrovascular effects of homocystine and folate supplementation are poorly understood
Experimental model | Male Sprague-Dawley rats (8 weeks old) (Samtaco, Osan, Korea)
Study design | Paralleled experimental-control trial
Final sample size | 4 per group
Duration | 8 weeks
Measurements / Endpoints / Outcomes of interest | Cerebral expression level of the glucose transporter protein (GLUT-1)
| Ultrastructural alterations in cerebral vasculature and % of damaged vessels: electron microscopy
Other outcomes reported | Plasma TBARS, Hcy, vitamin B12 and folic acid
| Weight gain, food intake, food efficiency ratio
Results | 8 weeks of folate supplementation significantly increased the cerebral GLUT-1 protein, which had been decreased by homocystine diet for 2 weeks and for 10 weeks (p<0.05)
| In the folate supplemented group damaged vessels such as annihilation of cell organelles, degeneration of mitochondrial bilayer, and perivascular detachment were also observed. Dietary supplementation with folate for 8 week (group HF) reduced the percentage of damaged vessels compared to a homocystine diet for 10 week (group H) but the percentage was still higher than in controls (group C)
Authors' Conclusions | It is likely that folic acid supplementation may reduce cerebrovascular damage induced in hyperhomocysteinemia by affecting cellular oxidative metabolism.
Quality | A
Limitations / Comments | Rats in folate diet group were fed a diet with Hcy for 2 weeks before changed to folate-supplmented diet. The original control rats were fed a diet without folate or Hcy for 2 weeks and then continued for another 8 weeks. For the purpose of this review, this comparison is not appropriate.
| All rats had induced hyperhomocystinemia before the dietary allocation.

Rejected articles that used immature animal models

Author, Year | Robertson, 1968
Central hypothesis/Stated Purposes of Study | To investigate the ultrastructural features of early brain stem lesions in thiamine-deficient rats
Hypothesis diagram
Experimental diets or reagents | Synthetic diet devoid of thiamine fed ad lib
Control diets or reagents | Above diet with daily subcutaneous injection of thiamine HCL 4mg/10 gm body weight
Study characteristics | Country: Canada
| Funding source: Medical Research Council of Canada
Gap in Knowledge | Known:
| Unknown:
Experimental model | Immature female hooded rats (Quebec Breeding Farms), weighing 50–65 gm at the outset
Study design
Final sample size | Experimental 114; Isocaloric Controls 38; Equal-Weight Controls 20; Treatment Controls (thiamine deficient animals given thiamine injection for 4 days) 11
Duration | Animals were killed at daily intervals between days 27 & 41 by intracardiac perfusion of 3% glutaraldehyde
Measurements / Endpoints / Outcomes of interest | Behavior; brain lesions
Other outcomes reported
Results | Thiamine deficient rats appeared well & continued to grow until about the 12^th^ day, after which there was reduction of food intake & gradual loss of weight of about 1.5 gm/day. Neurologic signs first appeared between days 28 & 35; abnormalities of posture and equilibrium were followed in 2 or 3 days by loss of the ability to right themselves when rolled over, and by frequent falling when stimulated to walk. Death followed in 1–3 days unless the animals had been perfused earlier. The control animals receiving daily injections of thiamine displayed no neurologic signs, & apart from weight changes, appeared normal.
| Of 68 thiamine-deficient rats perfused on Day 27 and subsequent days of the experiment, 37 exhibited neurologic signs, and 32 of these had lesions. In none of the 31 animals killed before neurologic signs appeared were histologic changes demonstrated.
| By light microscopy, minimal changes were seen in 6 rats, from days 28–33; they consisted of reticulated or vacuolated neuropil, frequent focal swelling s of myelin sheaths and some axon irregularities. In 20 rats (Days 33–36) there were small perivascular hemorrhages & marked edema. Six animals (Days 38–41) exhibited varying degrees of frank necrosis.
| By electron microscopy, early lesions consisted of swelling of perivascular glial processes, with watery cytoplasm. Subsequently, glial processes & cell bodies away from vessel walls became swollen; fluid accumulation in occasional myelin sheaths give rise to separation of lamellae and distention of the sheaths. Later, there was patchy loss of perivascular glial foot processes. A few foot processes contained small membrane bound vacuoles. Cytoplasm became swollen, cell membranes were discontinuous & organelles underwent disintegration and the extracellular space became markedly enlarged.
| None of the control rats demonstrated lesions in the brain stem by electron microscopy.
Authors' Conclusions | Not explicitly stated.
Quality | A
Limitations / Comments

Author, Year | Collins, 1970
Central hypothesis/Stated Purposes of Study | To evaluate the cerebellum in experimental animals rendered thiamine-deficient.
Hypothesis diagram | TD → glycogen accumulation within glial cells in the cerebellar molecular layer → neuronal damage or cerebellar degeneration
Experimental diets or reagents | Complete diet containing 0.25 mg of thiamine per kg of diet. In order to avoid death from the acute effects of thiamine deficiency, the animals were supplemented with intraperitoneal injections of thiamine hydrochloride containing “5γ” of thiamine or with Purina Rat Chow containing the same amount of thiamine.
Control diets or reagents | Pair-fed control: Purina Rat Chow was fed in daily amounts so as to reproduce the weight curve of the experimental animals
| Normal control: synthetic diet containing 1.0 g of thiamine per kg of diet replaced the Purina Rat Chow
Study characteristics | Country: US
| Funding source: National Institute of Neurological Diseases and Stroke
Gap in Knowledge | Known:
| Unknown: The relationship between thiamine deficiency and cerebellar degeneration
Experimental model | Sprague-Dawley albino rats of both sexes weighing 100–120 g
Study design | Paralleled experiment-controlled trial
Final sample size | 7 animals (In total? Or in experimental group?)
Duration | 30 weeks
Measurements / Endpoints / Outcomes of interest | Clinical signs
| Histological findings: the sections of the cerebellar vermis were studied by phase microscopy, and thin sections, following staining with lead hydroxide, were studies by electron microscopy.
Other outcomes reported
Results | Of the 7 animals studied, all showed ataxia at some time during the course of the experiment and were ataxic at the time of sacrifice.
| Cytoplasmic osmiophilic granules accumulation were found in glial cells in the molecular layer of the cerebellum; much less so in the granular layer; authors stated that this granular material is consistent with glycogen granules based upon their size and staining characteristics.
| Dendritic spines in contact with and surrounded by glycogen-filled glial processes showed signs of degeneration (the number of identifiable subcellular structures was markedly reduced).
Authors' Conclusions | In thiamine deficient albino rats, marked glycogen accumulation was found within cerebellar glial cells and in some areas this process is associated with neuronal degeneration.
Quality | B
Limitations / Comments

Author, Year | Nakagawasai, 2000
Central hypothesis/Stated Purposes of the study | To further clarify the correlation between changes in the level of SST in the brain, particularly in the hippocampus, and amnesia during TD
Hypothesis diagram | Thiamin deficiency → ↓ SST level in hippocampus → ↓ performance of passive-avoidance learning
Experimental diets or reagents | TD group: completely thiamine-deficient diet (CLEA Japan Inc., Tokyo, Japan) consisted of a basic ratio of 67.6% carbohydrate, 18% protein, and 8% lipid; it was supplemented with various vitamins, except for thiamine, and minerals
| Single treatment with thiamin HCl: TD rats were given a single thiamine HCl [0.5 mg/rat, subcutaneous (s.c.)] treatment on the 14^th^ or 21^st^ day
Control diets or reagents | Pair-feeding control: the animals were given the same amounts of food as the TD group, however, the food contained 1.6 mg thiamine HCl/100 g of diet (CLEA Japan Inc., Tokyo, Japan).
| Normal control group: the animals were allowed to freely take a complete normal diet containing thiamine.
Study characteristics | Country: Japan
| Funding source: No data
Gap in Knowledge | Known: Somatostatin (SST), a neuromodulator in the central nervous system, is rick in the cerebral cortex and hippocampus, which are integrative regions of cognitive function. Intracerebrally administered SST improves impairement of learning and memory of cysteamine-treated, scopolamine-treated, and nucleus basalis magnocellularis-lesioned rats in the passive-avoidance learning test. It has been demonstrated that brain SST is one of the most severely affected systems in patients with AD.
| Unknown: Brain SST may be suggested to play a facilitatory role in cognitive function
Experimental model | Male Wistar rats, weighting 75–85 g at the beginning of the experiment
Study design | Paralleled experiment-controlled trial
Final sample size | N=8 per group
Duration | 25 days
Measurements / Endpoints / Outcomes of interest | Step-through passive-avoidance task: the latency time of the retention trial was measured on the 14^th^ and 25^th^ day after start of the TD diet.
| Percentage of animals displaying impairment avoidance learning (entering in the dark compartment within 300 s on retention trial) was also recorded.
Other outcomes reported | SST content in the brain
Results | The latency time was not significantly changed on the 14^th^ day as compared TD rats with the pair-fed rats. On the 25^th^ day however, the latency time of the retention trial in the TD rats was significantly decreased as compared to the pair-fed rats (p<0.05)
| The % of avoidance learning impairment of the TD significantly increased on the 25^th^ day (p<0.05).
| The single thiamine HCL on the 14^th^ day reversed the latency time of the retention trial to the control level on the 25^th^ day (p<0.05). However, when the thiamine HCl treatment was given on the 21^st^ day, no reversal effect was observed for amnesia estimated on the 25^th^ day.
Authors' Conclusions | The present study showed that the amnesia as determined by passive-avoidance task was gradually induced over time after the start of TD feeding. Furthermore, the present data shows that this impairment of avoidance learning was completely reversed to an almost normal range merely by a single injection of thiamine HCl (0.5 mg/rat, s.c.) at a relatively early TD stage (14 days, and it remained reversed even with the continuation of the TD treatment until the 25^th^ day.
Quality | A
Limitations / Comments

Author, Year | Stewart et al, 1975
Stated Purpose of the Study | To study the behavioral effects of pyridoxine deficiency in postweanling rats
Hypothesis diagram
Experimental diets or reagents | Pyridoxine deficient diet
Control diets or reagents | 1 Pyridoxine deficient diet supplemented with 30 mg of Pyridoxine HCL/Kg of diet (ad lib); 2 Pyridoxine deficient diet supplemented with 30 mg of Pyridoxine HCL/Kg of diet (pair-fed)
Study characteristics | Country: US
| Funding source: No data
Gap in Knowledge | Known:
| Unknown:
Experimental model | Male rats of the Charles River CD strain, 3 wk old and 7 wk old
Study design | See original paper for details regarding the 7 separate experiments.
| The essential features of the apparatus used in the experiment included a start box, separated from the runway proper by a guillotine door, and a safety box with no grids on the floor at the end of the runway. The entrance to the goal box was also through a guillotine door. Shock could be delivered to the floor of the start box and runway but not to the safety box. At each trial both the doors were raised that activated a light and buzzer that served as a conditional stimulus. The conditinal stimulus remained on between the raising of the doors and the onset of the unconditional stimulus which was an electric shock. Both stimuli remained on until the rat escaped from the runway to the goal box at which time the stimuli were terminated.
Final sample size | See table 1 in original paper
Duration | 3–10 weeks, depending on the experiment
Measurements / Endpoints / Outcomes of interest | Avoidance response behavior
| Motor function (running time)
| Shock escape task
| Passive avoidance tack
Other outcomes reported
Results | 1 The acquisition of avoidance response over 6 days showed their means (ANOVA) to differ significantly (P<0.001). Scheffe tests showed that the pyridoxine deficient group differ significantly from the two control groups, which did not differ significantly from each other.; 2 Dietary deficiency had no effect on avoidance behavior in the developing animal until it had been fed the diet for at least 5 weeks.; 3 It took the control rats 15 trials before reaching the criterion of 9 avoidance responses over 10 consecutive trials; it took 27.4 trials in the pyridoxine deficient rats (P<0.01) to reach the same criterion.; 4 Deficient animals were slower to start running in response to the electric shock throughout the testing, and that both groups of animals showed improvement in their start times over the 30 trials of testing.; 5 Using running time as the measure, ANOVA showed that there was a main effect due to diet (P<0.05), due to trials (P<0.01) and an interaction between trials and diet (P<0.05). This interaction was due to the run times for deficient animals being faster than controls for the first block of 5 trials and slower than controls for the remaining blocks of trials.; 6 Animals were fed deficient or control diets from weaning until the end of week 8 when they were injected with intraperiotneally with pyridoxine 50 mg/Kg and then tested on the shock avoidance responses. The mean number of avoidance response in the deficient group was smaller than the control (P<0.01) at 3 days post injection; the mean number is not significantly different at 7 days.; 7 Deficiency was induced in young animals starting at 7 weeks of age, i.e. at 4 weeks beyond the weaning period; the deficient diet was continued for 7 weeks in one study, and for 10 weeks in another study. There was no significant difference in avoidance response between the two groups in both studies.; 8 Animals in another study were first trained to traverse up the runway for water reward and then punished with electric shock for making this response. ANOVA showed that the deficient animals had significantly faster running times (P<0.01). Both groups showed a significant reduction in running time over the 3 days (P<0.01).
Authors' Conclusions | Avoidance behavior in rats is affected by pyridoxine deficiency.
| Five weeks of pyridoxine deficiency was sufficient to produce a deficit in active avoidance learning in the postweanling animals whereas up to 10 weeks of deficient diet ingestion produced no effect on young adult animals.
| Mild motor impairment was produced in the young pyridoxne-deficient rats but the avoidance learning deficit could not be explained away on this basis, because a deficit in passive avoidance was also produced by the deficiency.
| Reversal of the deficiency by pyridoxine injection restored the active avoidance learning to normal within 1 week.
Quality | A
Limitations / Comments

Author, Year | Guilarte, 1991
Central hypothesis/Stated Purposes of the study | To quantitatively measure the effects of marginal vitamin B-6 nutrition during gestation, lactation, and postweaning on spontaneous locomotor activity of the developing rat.
Hypothesis diagram
Experimental diets or reagents | Vitamin B6 deficient diet: 0.7 mg/kg pyridoxine HCl
Control diets or reagents | Vitamin B6 sufficient diet: 7.0 mg/kg pyridoxine HCl
Study characteristics | Country: US
| Funding source: No data
Gap in Knowledge | Known: B-6 deficiency during gestation and lactation results in abnormal CNS development in neonatal animals and human infants.
| Unknown: Motor abnormalities, one of the most commonly described consequences of neonatal vitamin B-6 deficiency, have not been systematically studied.
Experimental model | Male pup Long-Evans rats at 14, 28, and 56 days of age
Study design | After 2–3 weeks on the specified diet, female rats were mated with male rats. Within 24 hours of birth, offspring were weighed and litter size culled to 8. Dams and offspring were maintained on their respective diet throughout the study.
Final sample size | N=6 per group
Duration | 56 days
Measurements / Endpoints / Outcomes of interest | Locomotor activity measurements: Behavioral data collection was automated using a Digiscan Animal Activity Monitor (Omnitech Model #RXYZCM) coupled to a Digiscan Analyzer (Omnitech Model DCM-8). 1 male pup per litter was randomly selected for behavioral study in the computerized Digiscan system. Measurements on the same rat were obtained at 14, 28, and 56 days of age.
Other outcomes reported
Results | The analysis of variance with repeated measures revealed that there were no significant dietary treatment effects for any of the locomotor activity variables measured.
| Further analysis of these overall interactions indicated that animals from the vitamin B6 restricted diet group demonstrated a pattern of hypoactivity at 14 days of age followed by hyperactivity postweaning. This effect is demonstrated for the measurements of horizontal activity, total distance, and number of vertical movements. Data for other behavioral measures showed a similar pattern of locomotor behavior.
Authors' Conclusions | The data clearly show 2 patterns of spontaneous locomotor behavior in the vitamin B6 restricted developing rat. In early neonatal life, vitamin B6 restriction produces a generalized hypoactivity in essentially all measures of locomotor behavior. The novel finding in the present study is that in the postweaning period, at 28, 56, and 196 days of age, the vitamin B6 restricted rats became hyperactive in many of the indices of horizontal, rearing, and stereotypic behavior. The degree of hyperactivity became more apparent as the animals aged with many more indices of locomotor behavior demonstrating hyperactivity.
Quality | B
Limitations / Comments | No proxy measure for how “deficient” of those vitamin B6 restricted rats. Perhaps there is no significant difference in B6 status between the 2 groups.
| Postweaning rats were used.

Author, Year | Ezer, 1976
Central hypothesis/Stated Purposes of the study | Vitamin B12 can promote the synthesis of RNA and of protein plays an important role in brain function, particularly in learning and memory
Hypothesis diagram | Vitamin B12 → promote the synthesis of RNA and of protein → improve learning and memory
Experimental diets or reagents | Animals were fed on a standard diet and vitamin B12 was administered intraperitoneally at doses of 4×1, 4×10, or 4×100 μg/kg
Control diets or reagents | Animals were fed on a standard diet and vitamin physiologic saline or water containing tween 80 was administered intraperitoneally
Study characteristics | Country: Hungary
| Funding source: No data
Gap in Knowledge | Known: The experimental methods elaborated for the laboratory investigation of the learning process on animals can mainly be divided into 2 groups, either being based on the consolidation of Pawlov's conditioned reflex, or applying Skinner's operant conditioning.
| Unknown: The effect of vincristine and vitamin B12 on brain function assessed by a new simple method called the tape test, which dose not require expensive instruments.
Experimental model | Female Wistar rats weighing 100–120 g. For those animals were selected (or learning-dull rats), which were unable to remove the tape within 60 s during 3 selections (on 3 successive days).
Study design | Parallel experiment-controlled study
Final sample size | Control 96
| Vitamin B12 4×1 μg/kg:36 4×10 μg/kg:36 4×100 μg/kg:84
Duration | N/A (intraperitoneally)
Measurements / Endpoints / Outcomes of interest | Problem-solving ability: the problem-solving times were measured on 4 successive days, with posttrial treatment. The problem-solving times are classified as follows: I (excellent) tearing off the tape in 1–20 s. II (good) tearing off the tape in 21–40s. III (poor) tearing off the tape in 41–59s. IV (without success) failure to tear off the tape in 60s.
| P.S. index = (sum of problem solving I × 100)/sum of problem solving IV
Other outcomes reported
Results | There was a dose-dependent effect of vitamin 12 on problem-solving ability in learning-dull rats. The results were expressed in 1–2 and 3–4 trial blocks. The change of P.S. index values (except 1 μg/kg vitamin B12) is significant larger than the control values. The problem-solving times were significantly shorter in rats received higher dose of vitamin B12.
| Compared to the control animals, the distribution of P.S.T 1–4 trial block in rats received 4×100 μg/kg vitamin B12 was significantly toward shorter time categories (p<0.01).
Authors' Conclusions | There is a stimulatory effect of vitamin B12 on problem-solving ability of the learning-dull rats and the effect is dose-dependent.
Quality | B
Limitations / Comments | The statistical methods were not reported. Not sure why the comparison arms are not balanced.
| Vitamin B12 was administered intraperitoneally

Author, Year | Sasaki et al, 1992; Sasaki et al, 1993
Central hypothesis | Acetylcholine contributes to learning and nicotine may improve learning in an acetylcholine deficient rat (data for this is not extracted in this table). The following data pertains to the effect of vitamin B12 on cognition in rats fed with a choline deficient diet.
Hypothesis diagram
Experimental diets or reagents | 1 choline enriched diet (4 mg/g); 2 choline deficient diet (0 mg/g); 3 choline deficient diet supplemented with vitamin B12 (10 mg/Kg)
Basal Diet | Basal diet: standard rat chow containing 1.6 mg/g of choline chloride
Study characteristics | Country: Japan
| Funding source: SRF Grant for Biomedical Research
Gap in Knowledge | Known:
| Unknown:
Experimental model | 4 wk old male Wistar rats fed above diets
Study design | On diet for 10 weeks, then tested for passive avoidance learning. Step-through procedure: an apparatus consists of two compartments (one illuminated, one dark) separated by a door; an animal was placed into the illuminated side and, through the door, could enter the dark side which has a grid floor; once all 4 paws are on the grid, an electric shock was delivered. The response latency in entering the dark compartment was measured. This learning was repeated on the 2^nd^, 3^rd^ and 4^th^ day.
Final sample size | 10 in each group
Duration | 10 weeks
Measurements / Endpoints / Outcomes of interest | Latency time in Passive avoidance learning
Other outcomes reported | Whole brain choline and acetylcholine
Results | Latency time in choline-deficient supplemented with vitamin B12 rats was significantly longer than that of the choline-deficient rats on the fourth day (P<0.05).
| Vitamin B12 increased tissue weight of the brain and content of acetylcholine in rats fed a choline-deficient diet.
Authors' Conclusions | Vitamin B12 facilitated acetylcholine synthesis or release in the brain and improved the cognitive disturbance.
Quality | B
Limitations / Comments | The improvement of cognitive disturbance may be due to intense input of shock stimuli. The study is not able to separate the learning improvement from increased shock sensitivity in the step-through procedure.
| Not preferred comparisons. For our purpose of this review, the best comparisons in this coline deficient diet supplemented with B12 vs. choline deficient diet.

Author, Year | Gospe et al., 1995
Central hypothesis/Stated Purposes of the study | The 1^st^ experiment describes the effect of folate deficiency on the histopathology of brain and skeletal muscle.
| The 2^nd^ experiment compares the growth, food spilling behavior and the concentrations of total folate, cysteine and homocysteine in serum, and of neurotransmitters in the hypothalamus and caudate nucleus from folate-deficient and control mice.
| The 3^rd^ experiment compares the growth, food spilling behavior and the concentrations of folate, SAM and S-adenosylhomocysteine (SAH) in whole brain and hematologic characteristics of folate-deficient and control mice
Hypothesis diagram
Experimental diets or reagents | Amino acid based diet supplemented with 0 μmol folic acid for 38 days
Control diets or reagents | Amino acid based diet supplemented with 11.3 μmol folic acid per kg diet for 38 days
Study characteristics | Country: US
| Funding source: USPHS, USDA & California Experiment Station
Gap in Knowledge | Known:
| Unknown:
Experimental model | Weanling Swiss Webster female mice
Study design | 2 groups of mice of equal mean body weights and randomly assigned to the two diets. Measurement of body weights, amount of food given, spilled by the mice and food left in the feed cup were almost all obtained daily. At the end of the feeding periods, the mice were killed by overdosing with diethyl ether and bled by cardiac puncture.
| Experiment 1, brains were removed and fixed in formalin for pathologic evaluation.
| Experiment 2, brains were removed, frozen in liquid nitrogen and weighed, caudate nuclei and hypothalamus were dissected from frozen coronal section. Samples were analyzed for neurotransmitters and their metabolites.
| Experiment 3, whole brains were frozen and analyzed for total-folate, S-adenosylhomocysteine and S-adenosylmethionine.
Final sample size | Exp 1: 2 from folate-deficient group and 1 from the control group (not clearly reported)
| Exp 2: 5 in each group (only 4 of each were analyzed, data for one deficient and one control mouse were omitted because they spilled very little food)
| Exp 3: 7 in each group
Duration | Exp 1: 38 days
| Exp 2: 37 days
| Exp 3: 39 days
Measurements / Endpoints / Outcomes of interest | Histological findings
| Neurotransmitters in the hypothalamus and caudate nucleus from folate-deficient and control mice
Other outcomes reported | Weight loss, food spilling behavior, and the concentrations of total folate, cysteine and homocysteine in serum,
Results | 1 After approximately 3.5 wk on the folic-acid deficient diet, growth rate declined and these mice eventually lose weight.; 2 In Exp 2, at the end of the 37 day feeding period, folate-deficient animals weighed ~70% of the control mice (p=0.01). This was consistent among the 3 studies.; 3 In Exp 2, the cumulative food spilled over the 37 day period in the folate-deficient group was 166 ± 21 g vs. 52 ± 11 g in the control (p=0.0015).; 4 In Exp 2, the folate deficient group consumed 219 ± 21 g while the control consumed 174 ± 4 g (p=0.039). Even though the folate deficient animals spilled more food, and gained less weight, they actually consumed more food during the course of the experiment. Similar observations were recorded in Exp 3.; 5 Serum folate in the animals fed folic acid deficient diet were reduced to <5% of the control (p=0.0001).; 6 Brain and spinal cord showed no apparent pathologic changes in folate-deficient animals.; 7 Gastrocnemius and soleus muscles from folate deficient mice showed a reduction in the number of larger fibers compared to control mice.; 8 Differences in hypothalamic concentrations of norepinephrine, dopamine, or their metabolites between deficient and control mice were not significant. Caudate dopamine levels were reduced by 36% (p=0.04), 3,4-dihydroxyphenylacetic acid (DOPAC) by 48% (p=0.03), and homovanillic acid (HVA) by 43% (p=0.047) in folate-deficient mice. The 5-hydroxyindole acetic acid (5-HIAA)/ serotonin (5HT) ratio was lower in folate deficient mice compared to control (p=0.015).; 9 Animals fed folic acid deficient diet had significantly lower whole brain folate and SAM; whole brain folate was 47% lower (p=0.01) and SAM was 40% lower (p=0.035). Whole brain (s-adenosyl homocysteine) SAH was not affected, however SAM (s-adenosyl methionine) /SAH ratio was 43% lower (p=0.047)
Authors' Conclusions | The combination of weight loss and augmented food consumption suggests that folate depletion may reduce the efficiency by which animals utilize dietary nutrients to meet physiological functions, suggesting that an alteration in hypothalamic and/or neuroendocrine function may underlie this effect of folate depletion. In addition, these changes may be due to a folate deficiency induced reduction in nutrient absorption.
| These studies were designed to characterize the food spilling behavior of folate deficient mice and to determine if it might have a neurochemical basis. Precautions were taken to minimize the effects of diurnal variation on the results of this study. These included housing the mice in a room with a 12 h light dark cycle, feeding and weighing the mice at the same time each day and alternately killing control and deficient mice within a 2 h window at the end of each experiment.
Quality | B
Limitations / Comments | The feeding patterns during the dark cycle were not monitored. Exp 3 has no outcome of interests to this review.

## B Vitamin Evidence Tables - Human Studies

Intervention

Author, Year: Abyad, 2002 | Ref ID: 53 | Vitamins: B12
Objective: To determine whether dementia is associated with low serum B12 levels and whether treatment of demented patients with low level of serum B12 have any impact on memory

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Prospective longitudinal | Age: | 82 | N/A | Nursing home residents and outpatients with Dx of dementia and low serum B12 level (<300 pg/mL) | ND | AD:
Country: | Lebanon | %Male: | 36 | N/A | | | PD:
Setting: | Nursing home and outpatient clinic | Race: | | | | | VascDz:
Funding: | ND | Other: | | | | | Other: According to the established criteria
Comments: No definition for dementia type is provided

Intervention(s): | Control: N/A | | Total | Intervention 1 | Intervention 2 | Control
B12: 1000 μg iv daily for 1 week; then weekly for 1 month; then monthly thereafter | | N enrolled: | 62 | 62
| | N analyzed: | 56 | 56
| | Drop-outs (%): | 6 (11) | 8 (14)
Follow-up duration: 12 months | | Reasons for drop out: death: 2; ND: 4
Comments:

Primary outcome(s): | Folestein MMSE (23–27: mildly impaired; 19–23: moderately impaired; ≤19: severely impaired)
Secondary outcome(s):
Adverse events: | ND
Limitations: | No normal (without dementia) control group; small sample size; power calculation not reported
Quality (A/B/C): C | Applicability (1/2/3): 1

Outcome(s): | Results (Text) (or Definition)
MMSE | At 3 months to 12 months of follow-up, 40 /56 subjects improved in their mental status score. Six subjects gained 1,2,3,6, and 9 points, respectively, and essentially normalized their scores. Three patients maintained their score after 1 year of follow-up. The only clinical feature that predicted amelioration in MMSE following treatment was a short duration of pre-treatment mental symptoms

All Subjects

Outcome | MMSE | | (0–100)
| | N | B12 | 1000 μg iv | N | (Intervention) | (Dose) | N | (Intervention) | (Dose) | N | Control
Baseline value | (SE/SD) | 56 | 14.5 | 7.7
Final value | (SE/SD) | 56 | 15 | 9.9
Difference | (SE/SD/95% CI) | +0.5 | | 2.12
P Difference | | ND
Net Difference | (SE/SD/95% CI)
P Net difference

Short Symptom Duration*

Outcome | MMSE | | (0–100)
| | N | B12 | 1000 μg iv | N | (Intervention) | (Dose) | N | (Intervention) | (Dose) | N | Control
Baseline value | (SE/SD) | 22 | 19 | 5
Final value | (SE/SD) | 22 | 25 | 4
Difference | (SE/SD/95% CI) | +6 | | ND
P Difference | | 0.0065
Net Difference | (SE/SD/95% CI)
P Net difference

* MMSE score of patients with short (<12 months) pre-treatment symptom duration; adjusting for age, level of education, or serum B12 level in repeated measures analysis of covariance did not alter the significance of this relationship

Long Symptom Duration**

Outcome* | MMSE | | (0–100)
| | N | B12 | 1000 μg iv | N | (Intervention) | (Dose) | N | (Intervention) | (Dose) | N | Control
Baseline value | (SE/SD) | 34 | 18 | 4
Final value | (SE/SD) | 34 | 22 | 2
Difference | (SE/SD/95% CI) | +4 | | ND
P Difference | | 0.25
Net Difference | (SE/SD/95% CI)
P Net difference

** MMSE score of patients with long (>12 months) pre-treatment symptom duration

Intervention

Author, Year: Aisen, 2003 | Ref ID: 75 | Vitamins: Folate, B6, B12
Objective: Effect of multi-B vitamin on Hcy and cognitive function

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Prospective longitudinal cohort | Age: | 70.8+/-9.4 | | Medically stable, probable AD | Significant renal insufficiency (Cr>1.5 mg/dL), history of B12 or folate deficiency, use of vitamin supplement containing >400 μg folate, regular use of B12 injections, or medications known to influence homocysteine metabolism (eg, methotrexate, azathioprine, phenytoin) | AD: NINCDS-ADRDA
Country: | US | %Male: | 36% | | | | PD:
Setting: | Clinics | Race: | | | | | VascDz:
Funding: | Government | AD duration: | 3.3+/-2.5 yr | | | | Other:
Comments: Open label

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Folate 5 mg | | N enrolled: | 69
Vitamin B12 1 mg | | N analyzed: | 63
Vitamin B6 50 mg | | Drop-outs (%): | 9%
Follow-up duration: 8 wk | | Reasons for drop out: nd
Comments: Compliance, by pill count exceeded 80%

Primary outcome(s): | Homocysteine level
Secondary outcome(s): | MMSE, Alzheimer Disease Assessment Scale cognitive subscale (ADAScog), Geriatric Depression Scale
Adverse events: | No serious adverse events and in no instance was the vitamin regimen discontinued as a result of adverse events. In no instance was an adverse symptom judged to be related to the study intervention.
Limitations:
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text) (or Definition)

Outcome | MMSE | | (0–30)
| | N | Multivitamin | | N | (Intervention) | (Dose) | N | (Intervention) | (Dose) | N | Control
Baseline value | (SD) | 63 | 19.2 | 7.0
Final value | (SD) | 63 | 19.3 | 7.7
Difference
P Difference | | NS
Net Difference
P Net difference
(RR/OR/HR)
P (RR/OR/HR)

Lack of association between multivitamin use and cognitive decline (unclear if MMSE or ADAScog) was not affected by controlling for baseline Hcy.

Intervention

Author, Year: Blass, 1988 | Ref ID: 330 | Vitamins: Thiamine
Objective: Effect of high dose thiamine on cognitive function in patients with AD

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Randomized Xover | Age: | 72 | | Dementia clinic with diagnosis of AD | Cerebrovascular disease; Hachinski score (for multi-infarct dementia) >4 | AD: National Institute of Neurological and Communicative Disorders and Stroke-Alzheimer's Disease and Related Disorders Association criteria for “probable AD”
Country: | US | %Male: | 36% | | | | PD:
Setting: | Specialty clinic | Race: | nd | | | | VascDz: nd
Funding: | NIH, private | Other: | | | | | Other:
Comments:

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Thiamine HCl 1 g TID | Niacinamide 250 mg TID | N enrolled: | 16
| | N analyzed: | 11
| | Drop-outs (%): | 31%
Follow-up duration: 3 mo | | Reasons for drop out: 2 hospitalized; 3 required antidepressant
Comments: Randomization performed by pharmacy

Primary outcome(s): | MMSE, Blessed Score, Haycox Score
Secondary outcome(s):
Adverse events: | None
Limitations: | Small sample size, incomplete description of sample or outcomes
Quality (A/B/C): C | Applicability (1/2/3): 1

Outcome(s): | Definition
MMSE | Mini-Mental State Examination, completed by nurse
Blessed Score | Behavioral rating, completed by nurse (Blessed et al. The association between quantitative measures of dementia and senile change in the cerebral gray matter of elderly subjects. Br J Psychiatry 1968; 114:797–811)
Haycox Score | Behavioral rating, competed by caretaker (Haycox et al. A simple, reliable clinical behavioral scale for assessing demented patients. J Clin Psychiatry 1984;45:23–4)

Outcome | MMSE | | (score)
| | N | Thaimine | 3 g/day | | | N | Control (Niacinamide)
Baseline value | (SEM) | 11 | 14.2 | -1.4 | | | 11 | same
Final value | (SEM) | 11 | 15.5 | (1.5) | | | 11 | 14.7 | (1.6)
Difference | (SEM) | +1.35 | | (0.67) | | | +0.54 | | (0.68)
P Difference | | 0.08 | | | | | 0.45
Net Difference | (SEM) | +0.72 | | (0.14)
P Net difference | | <0.001

Outcome | Blessed | | (score)
| | N | Thaimine | 3 g/day | | | N | Control (Niacinamide)
Baseline value | (SEM) | 11 | 7.41 | (0.81) | | | 11 | same
Final value | (SEM) | 11 | 7.55 | (1.00) | | | 11 | 6.93 | (0.86)
Difference | (SEM) | +0.14 | | (0.64) | | | -0.48 | | (0.74)
P Difference | | 0.83 | | | | | 0.27
Net Difference | (SEM) | +0.62 | | (0.52)
P Net difference | | 0.27

Outcome | Haycox | | (score)
| | N | Thaimine | 3 g/day | | | N | Control (Niacinamide)
Baseline value | (SEM) | 11 | 11.1 | (1.2) | | | 11 | same
Final value | (SEM) | 11 | 13.4 | (1.8) | | | 11 | 12.2 | (1.4)
Difference | (SEM) | +2.29 | | (1.40) | | | +1.10 | | (1.20)
P Difference | | 0.13 | | | | | 0.40
Net Difference | (SEM) | +1.21 | | (0.81)
P Net difference | | 0.17

“Subjectively, no important clinical changes were observed in these moderately impaired patients during their 3 months of receiving thiamin (nor with the niacinamide placebo)”

Intervention

Author, Year: Carmel, 1995 | Ref ID: 10010 | Vitamins: B12
Objective: Effects of cobalamin replacement on dementia patients

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Studydesign | Cohort | Age: | 71 | | Dementia patients, low cobalamin levels < 190 ng/l | ND | AD:
Country: | USA | %Male: | 25 | | | | PD:
Setting: | Outpatient facilities for dementia, affiliated w/university & VA medical center | Race: | ND | | | | VascDz:
Funding: | Government | Other: | | | | | Other:
Comments: Subjects grouped by DSM-III-R criteria into following categories: probable AD, possible AD, and other dementia; controls include PD w/o dementia; cobalamin assay with reference interval 90–1016 ng/l - established by 332 healthy volunteers

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Cyanocobalamin 1000 μg IM per wk × 8 wk, then per mo for ≥4 mo | | N enrolled: | | 16*
| | N analyzed: | | 14
| | Drop-outs (%):
Follow-up duration: 1 follow-up after 6–8 months therapy | | Reasons for drop out:
Comments: *34 AD pts with low cobalamin levels - unclear how many were actually enrolled. Stated 9 pts fully studied, 7 partially studied, remainder refused further tx, were on cobalamin prior to being studied, or did not comply with tx. CERAD battery pre-treatment found variable degrees of dementia in 13 pts & 3 nondementia pts

Primary outcome(s): | Neuropsychological outcomes via CERAD battery results including MMSE, 15-item naming task, verbal fluency task, verbal memory task, visuoconstructive task
Secondary outcome(s):
Adverse events:
Limitations:
Quality (A/B/C): C | Applicability (1/2/3): 1

Outcome(s): | Results (Text)
Neuropsychologic | Report only overall improvement/worsening in cognitive testing (N=14)
| Improved or became normal - 1 (improvement in several CERAD tasks)
| No change - 12
| Worse - 1 (functional progression of dementia, CERAD results did not change noticeably)

Intervention

Author, Year: Deijen, 1992 | Ref ID: 10006 | Vitamins: B6
Objective: Effect of B6 supplementation on memory etc.

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | RCT | Age: | 73 | 73 | Male, 70–79 yr, healthy, EtOH<4/day, IQ>80 | Drugs that affect B6 metabolism, drugs affecting immune reactivity, B6 supplement within 3 mo, auto-immune diseases, long-acting hypnotics or anti-depressants within 1 mo, drug or EtOH addiction, abnormal chemical/hematological profile, sensory or motor defect that may affect testing. | AD:
Country: | Netherlands | %Male: | 100 | 100 | | | PD:
Setting: | Population | Race: | nd | nd | | | VascDz:
Funding: | nd | PLP | 31 | 29 | | | Other:
| | α-EAST | 1.75 | 1.83
| | IQ | 109 | 111
Comments: Subjects paired by age, vitamin B6 status and IQ, then randomized.

PLP: plasma pyridoxal-f'-phosphate; α EAST: erythrocyte enzyme aspartate aminotransferase activation

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Vitamin B6 (pyridoxine HCl) 20 mg per day | Placebo (identical capsules) | N enrolled: | 82 | 41 | | 41
| | N analyzed: | 76 | 38 | | 38
| | Drop-outs (%): | 7%
Follow-up duration: 12 wk | | Reasons for drop out: 3: illness; 3 were matched subjects to the ill ones
Comments: Complicated statistical analyses performed. Different for each outcome. Suggests that authors may have been fishing for significant results.

Primary outcome(s): | Cognitive functioning
Secondary outcome(s): | Pupil size as measure of mental effort, B 6 status, mood
Adverse events: | nd
Limitations: | Non-standardized tests. Questionable statistics. Incompletely reported data.
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text) (or Definition)
Associate Learning Task | Test of short term verbal memory, remembering name-occupation pairs (9 pairs)
Associate Recognition Task | Test of long term verbal memory, same as Associate Learning Task with 1 hr delay (9 pairs)
LongTermMemory Storage | Difference (by subtraction) between Associate Learning and Recognition Tasks (what is forgotten) (9 pairs)
Short Term Memory Task (Pupilometry) | Pupil diameter measured during timed memory/visual recognition test. Measures “mental effort” as a combination of phasic pupil response, reaction times and number of correct responses. (41 trials)
Speed of Processing Task (Pupilometry) | Pupil diameter measured during timed task requiring choosing button on opposite corner of displayed marker. Measures “mental effort” as a combination of phasic pupil response, reaction times and number of correct responses (51 trials)

Outcome | Associate Recognition Task | | | | (0–9) | | Reported graphically
| | N | B6 | 20 mg | | | N | | Placebo
Baseline value | (SD) | 38 | 3.2 | (2.3) | | | 38 | 3.9 | (2.1)
Final value | (SD) | 38 | 3.3 | (2.3) | | | 38 | 2.8 | (2.0)
Difference
P Difference | | NS
Net Difference
P Net difference

Outcome | | Long Term Memory Storage (Forget Score) | | | (0–9, low score better) | | Reported graphically
| | N | B6 | 20 mg | | | N | | Placebo
Baseline value | (SD) | 38 | 0.35 | (1.4) | | | 38 | 0.45 | (2.1)
Final value | (SD) | 38 | 0 | (1.4) | | | 38 | 0.9 | (2.1)
Difference
P Difference | | P<0.03
Net Difference
P Net difference

Associate Learning Task: Multivariate one-way ANCOVA did not show a multivariate difference between groups.

Mental Effort Tests: Number of correct responses and reaction times on speed of processing task and memory task were the same for both groups. Pupillary responses were the same for both groups.

Intervention

Author, Year: Fahn, 1974 | Ref ID: 938 | Vitamins: Pyridoxine
Objective: Effect of pyridoxine on L-Dopa in patients with PD and severe “on-off” effects

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Prospective longitudinal cohort (Xover) | Age: | 53 (40–64) | | Idiopathic PD, severe on-off effects such that they could no longer function normally. (Initial excellent response to L-Dopa, then choreic movements developed, then on-off: sudden loss of effectiveness with abrupt onset of akinesia followed by equally sudden return of effectiveness). Stabilized for at least 7 days on L-Dopa or Carbidopa/L-Dopa doses. | (Amantadine discontinued) | AD:
Country: | US | %Male: | 60% | | | | PD: | nd
Setting: | Clinic (admitted for study) | Race: | nd | | | | VascDz:
Funding: | Government, Pharmaceutical | Other: | 1.5-3yL-Dopa 2 post-thalamotomy | | | | Other:
Comments:

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Pyridoxine 100 mg IM with L-Dopa (1 dose) | L-Dopa alone | N enrolled: | 5 | 5 | | 5
Pyridoxine 100 mg IM with Carbidopa/L-Dopa (1 dose) | Carbidopa/L-Dopa alone | N analyzed: | 5 | 5 | | 5
| | Drop-outs (%):
Follow-up duration: 1 dose each, separated by at least 7 days | | Reasons for drop out:
Comments:

Primary outcome(s): | Plasma levels of Dopa, homovanillic acid (HVA), 3-O-methyldopa (OMD),
Secondary outcome(s): | Clinical state (not clearly defined)
Adverse events:
Limitations:
Quality (A/B/C): | Applicability (1/2/3): 3

Outcome(s): | Results (Text) (or Definition)
Clinical state | No alteration in clinical state after a single dose of pyridoxine intramuscularly either while receinving L-Dopa alone or with Carbidopa
HVA, OMD | No change in plasma levels after a single dose of pyridoxine intramuscularly (shown graphically from 9 am to ~4 pm in 3 patients)
Dopa | Dopa consistently decreased slightly with pyridoxine compared to no pyridoxine (shown graphically from 9 am to ~6 pm in 3 patients)
| Effect not seen with combination Carbidopa/L-Dopa

Intervention

Author, Year: Fioravanti,1997 | Ref ID: 10007 | Vitamins: Folate
Objective: To evaluate the effect of folate supplementation on cognitive deficits fo aged patients in a controlled trial

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | RCT | Age: | 80.25 (5.78) | 80.21 (5.45) | Patients recruited among the elderly (70–90 yr) living either at home or in a community and had folate below 3 ng/mL and diagnosed to have mild to moderate severity of cognitive decline as assessed by Global deterioration scale | Patients with gastrointestinal, endocrine, CVD, or renal pathology, diagnosed with depression, with no cognitive decline (MMSE >24) or with a clear diagnosis of dementia (MMSE <16). And also those with regular intake of vitamins or of more than 55g of alcohol | AD:
Country: | Italy | %Male: | 25% | 8% | | | PD:
Setting: | Community and conducted by authors in an academic setting | Race: | ND | ND | | | VascDz:
Funding: | nd | Other: weight in Kg | 63.88 (14.42) | 57.29 (10.56) | | | Other: Cognitive impaired | MMSE score 16–24
Comments:

Intervention(s): | Control: | | Total | Intervention 1 Folate | Intervention 2 | Control Placebo
Folic acid 15 mg/d po | Placebo similar to the intervention | N enrolled: | 30 | 16 | | 14
| | N analyzed: | 30 | 16 | | 14
| | Drop-outs (%): | 0%
Follow-up duration: 60days | | Reasons for drop out:
Comments: No cognitive enhancer drugs or other treatments active on the CNS were allowed during the treatment period

Primary outcome(s): | Randt Memory Test: a multidimensional memory test consisting of 5 different tasks
Secondary outcome(s):
Adverse events: | ND
Limitations: | Small sample and short duration of treatment
Quality (A/B/C): B | Applicability (1/2/3): 2

Outcome(s): | Results (Text) (or Definition)
Cognitive improvement | Greater folate deficiency at the beginning of treatment was related to greater cognitive improvement after 2 months of treatment. However there was a lack of correlation between severity of folate deficiency and severity of cognitive decline at the baseline evaluation.

Blood folate level at baseline

| N= | Mean | SD
Folate treatment group | 16 | 2.34 | 0.51
Placebo treatment group | 14 | 2.21 | 0.68

Outcome | | Acquisition and recall (part of Randt Memory Test) | | | nd on scale
| | N | Folate po | 15 mg | N | | Placebo
Baseline value | (SE/SD) | 16 | 55.31 | 12.06 | 14 | 62.07 | 14.70
Final value | (SE/SD) | 16 | 59.56 | 12.53 | 13 | 60.85 | 18.81
Difference | (SE/SD/95% CI)
P Difference | | NS
Net Difference | (SE/SD/95% CI)
P Net difference | | <0.007
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

Outcome | | Delayed recall (part of Randt Memory Test) | | | nd on scale
| | N | Folate po | 15 mg | N | Placebo
Baseline value | (SE/SD) | 16 | 56.06 | 11.16 | 14 | 63.0 | 15.23
Final value | (SE/SD) | 16 | 63.44 | 13.9 | 13 | 63.0 | 19.27
Difference | (SE/SD/95% CI)
P Difference | | NS
Net Difference | (SE/SD/95% CI)
P Net difference | | <0.007
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

Outcome | | Memory index (part of Randt Memory Test) | | | nd on scale
| | N | Folate po | 15 mg | N | | Placebo
Baseline value | (SE/SD) | 16 | 49.25 | 12.26 | 14 | 57.07 | 15.59
Final value | (SE/SD) | 16 | 56.06 | 13.90 | 13 | 56.54 | 21.38
Difference | (SE/SD/95% CI) | NS
P Difference
Net Difference | (SE/SD/95% CI)
P Net difference | | <0.002
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

Outcome | | Encoding (part of Randt Memory Test) | | | nd on scale
| | N | Folate po | 15 mg | N | | Placebo
Baseline value | (SE/SD) | 15 | 4.33 | 2.11 | 14 | 5.29 | 2.33
Final value | (SE/SD) | 16 | 4.79 | 1.72 | 13 | 5.08 | 3.29
Difference | (SE/SD/95% CI) | NS
P Difference
Net Difference | (SE/SD/95% CI)
P Net difference | | <0.005
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

Outcome | | Cognitive efficiency (part of Randt Memory Test) | | | nd on scale
| | N | Folate po | 15 mg | N | | Control
Baseline value | (SE/SD) | 16 | 3.28 | 1.77 | 14 | 4.25 | 2.33
Final value | (SE/SD) | 16 | 3.91 | 2.62 | 13 | 4.31 | 2.87
Difference | (SE/SD/95% CI)
P Difference | | NS
Net Difference | (SE/SD/95% CI)
P Net difference | | NS
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

Outcome | | Attention efficiency (part of Randt Memory Test) | | | nd on scale
| | N | Folate po | 15 mg | N | | Placebo
Baseline value | (SE/SD) | 16 | 6.4 | 0.77 | 14 | 6.83 | 1.10
Final value | (SE/SD) | 16 | 7.52 | 1.48 | 13 | 6.9 | 1.24
Difference | (SE/SD/95% CI)
P Difference | | <0.05
Net Difference | (SE/SD/95% CI)
P Net difference | | NS
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

Intervention

Author, Year: Hsu, 1973 | Ref ID: 1401 | Vitamins: B6
Objective: Interaction of B6 and L-DOPA in PD

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Prospective longitudinal cohort | Age: | 57–76 | | Cases: PD, treated with L-Dopa 3–6 g/day during the previous 2 yr | Cases: Cardiac, renal or hepatic disease | AD:
Country: | US | %Male: | nd | | | | PD: | nd
Setting: | Outpatient (in metabolic ward) | Race: | nd | | | | VascDz:
Funding: | Private; Merck, Sharp and Dohme | Other: | | | | | Other:
Comments: Trial also done in 4 healthy controls.

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
L-Dopa 2 g/day × 7 days, Pyridoxine 150 mg/day, days 8–9 | none | N enrolled: | 5 | 5 | | 0
| | N analyzed: | 5 | 5 | | 0
| | Drop-outs (%):
Follow-up duration: 2 days | | Reasons for drop out:
Comments: Metabolic study

Primary outcome(s): | Urinary excretion of Dopa and Dopa metabolites (Dopa, Dopamine, dihydroxyphenylacetic acid [DOPAC], Homovanillic acid [HVA])
Secondary outcome(s): | Parkinsonian symptoms
Adverse events:
Limitations: | Small sample size, short duration, clinical outcomes not measured in systematic fashion
Quality (A/B/C): C | Applicability (1/2/3): 3

Outcome(s): | Results (Text) (or Definition)
24 hr urinary excretion of Dopa and metabolites | Simultaneous administration of pyridoxine and L-Dopa significantly decreased urinary excretion of Dopa and increased excretion of Dopa metabolites (though dopamine was not significantly increased in 24 hour urine).
Parkinsonian symptoms | Deterioration of symptoms in 2 of 5 patients, manifested by increased tremor, which persisted for 24 hr after discontinuation of pyridoxine.

24 hour urine excretion

| | N | DOPA | mg | Dopamine | mg | DOPAC | mg | HVA | mg
Baseline value | (SD) | 5 | 51.5 | 4.3 | 150.3 | 50.0 | 57.0 | 26.0 | 211.0 | 112.3
Final value | (SD) | 5 | 35.5 | 3.1 | 174.1 | 51.8 | 95.3 | 25.2 | 318.0 | 172.5
Difference
P Difference | | <0.02 | | | <0.10 (NS) | | <0.02 | | <0.05

Intervention

Author, Year: Hvas, 2004 | Ref ID: 1414 | Vitamins: B 12
Objective: To assess the cognitive function and symptoms of depression in individuals with elevated plasma methyl malonic acid (P-MMA)

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | RCT | Age: | 75 | 74 | Elevated plasma methyl malonic acid (P-MMA) | nd | AD:
Country: | Denmark | %Male: | 33% | 35% | | | PD:
Setting: | University | Race: | Nd | nd | | | VascDz:
Funding: | Private and meds Industry | Other: CAMCOG | 89 | 89 | | | Other: | Cognitively impaired
Comments: The Cambridge Cognitive Examination (CAMCOG) assesses broad range of cognitive functions and contains 60 items and in Danish individuals mean score <90 is cognitively impaired

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Cynacobalamin 1 mg IM | Isotonic sodium chloride 1 ml | N enrolled: | 140 | 70 | | 70
| | N analyzed: | 140 | 70 | | 70
| | Drop-outs (%): | 0%
Follow-up duration: 4 wk treatment and 3 mo follow-up | | Reasons for drop out:
Comments:

Primary outcome(s): | The Cambridge Cognitive Examination (CAMCOG); Mini mental Status examination; 12 word learning test
Description of outcomes | MMSE a score below 25 indicates cognitive impairment; 12 word learning test is sensitive for short term memory
Secondary outcome(s): | Plasma tHcy
Adverse events: | nd
Limitations:
Quality (A/B/C): A | Applicability (1/2/3): 2

P-MMA and P-tHcy measurement methods available

Outcome(s): | Results (Text) (or Definition)

CAMCOG | | (0–100)
| | N | B 12 | 1 mg | N | 1 mg Isotonic sodium chloride
Baseline value | (SE/SD) | 70 | 89 | | 70 | 89
Final value | (SE/SD) | 70 | | | 70
Difference | (SD) | +1.3 | | 4.8 | +1.9 | 4.3
P Difference | | 0.04 | | | 0.001
Net Difference | (95% CI) | -0.6 | (-2.2, +0.9)
P Net difference | | NS

Outcome | MMSE | (0–100)
| | N | B 12 | 1 mg | N | 1 mg Isotonic sodium chloride
Baseline value | (SE/SD) | 70 | 26 | | 70 | 27
Final value | (SE/SD) | 70 | | | 70
Difference | (SD) | +0.3 | | 2.3 | 0.2 | 1.7
P Difference | | NS | | | NS
Net Difference | (95% CI) | +0.1 | | -0.6; +0.8
P Net difference | | NS

12 word learning test, immediate | | 0–12
| | N | B 12 | 1 mg | N | 1 mg Isotonic sodium chloride
Baseline value | (SE/SD) | 70 | 5 | | 70 | 5
Final value | (SE/SD) | 70 | | | 70
Difference | (SD) | +0.2 | | 1.4 | +0.4 | 1.7
P Difference | | NS | | | 0.04
Net Difference | (95% CI) | -0.2 | | -0.7;+0.3
P Net difference | | NS

12 word learning test, 15 min | | 0–12
| | N | B 12 | 1 mg | N | 1 mg Isotonic sodium chloride
Baseline value | (SE/SD) | 70 | 2 | | 70 | 2
Final value | (SE/SD) | 70 | | | 70
Difference | (SD) | +0.2 | | 0.35 | +0.7 | 1.7
P Difference | | NS | | | 0.001
Net Difference | (95% CI) | -0.5 | | -1.1; -0.02
P Net difference | | 0.04

Intervention

Author, Year: Ikeda, 1992 | Ref ID: 1431 | Vitamins: B12
Objective: IV B12 for AD

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Prospective longitudinal cohort | Age: | 71+/-13 | | Alzheimer-type senile dementia or AD | History of serious diseases | AD: DSM III, NINCDS-ADRDA
Country: | Japan | %Male: | 40% | | | | PD:
Setting: | Unclear | Race: | Japanese | | | | VascDz:
Funding: | nd | Other: | | | | | Other:
Comments:

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
IV mecobalamin 500 μg 3x/week × 8 wk | None | N enrolled: | | 10
| | N analyzed: | | 10
| | Drop-outs (%):
Follow-up duration: 12 wk | | Reasons for drop out:
Comments:

Primary outcome(s): | MMSE, Mattis' Dementia Rating Scale
Secondary outcome(s): | Other scales: Modified Gottfries-Brane-Steen scale (M-GBS), Hasegawa's Dementia Rating Scale (HDS), Hamilton Depression Scale, Subjective symptoms, Neurological symptoms, Activities of daily living, Caregiver evaluation, Overall evaluation
Adverse events: | No side effects were detected in the laboratory tests nor were there any patient complaints.
Limitations:
Quality (A/B/C): C | Applicability (1/2/3): 1

MMSE | | (0–30) | | | Data Presented Graphically Only
| | N | IV Mecobalamin | 500 μ 3x/wk | N | N | N | Control
Baseline value | (SD, implied) | 10 | 20 | 7
Final value, 8 wk | (SD, implied) | 10 | 21 | 8
Post-Tx, 12 wk | (SD, implied) | 10 | 20 | 7
Difference | (SE/SD/95% CI)
P Difference | | NS (all time points)

Mattis' DMR (Japanese Version), Total | | (0–150) | | | Data Presented Graphically Only
| | N | IV Mecobalamin | 500 μg 3x/wk | N | N | N | Control
Baseline value | (SD, implied) | 10 | 112 | 25
Final value, 8 wk | (SD, implied) | 10 | 115 | 25
Post-Tx, 12 wk | (SD, implied) | 10 | 115 | 27
Difference | (SE/SD/95% CI)
P Difference | | <0.05 (all time points)

Outcome(s): | Results (Text) (or Definition)
DMR, sub-scales | Significant increase in Memory (P<0.05)
| No significant change in Attention, Intention & Perseveration, Construction, Conceptualization.
Modified GBS | Significant improvements in Intellectual functions, Emotional functions, and Total (P<0.05).
| No significant change in Initiatives, Different symptoms common in dementia, or Motor function.
Hasegawa's Dementia Rating Scale (HDS) | Significant improvement in scale (P<0.05)
Subjective symptoms (insomnia) | Before treatment 6/10 complained of insomnia; all 6 had improvement in sleep.
Neurological symptoms | 6/10 had symptoms before treatment. Improvement was seen in 2 who had sensory disturbances.
| The remaining 4 had no change.
Activities of Daily Living | No significant changes were apparent with treatment.
Caregiver evaluation (list of items) | 3/10 improved, 5/10 slightly improved, 2/10 no change. None deteriorated.
| Items that improved considerably after mecobalamin administration were talkativeness and ability to take initiative.
Overall evaluation (not defined) | 3/10 moderately improved, 6/10 slightly improved, 1/10 no change.

Intervention

Author Year: Ito 2001 | Ref ID: 1451 | Vitamins: B12
Objective: B12 in Alzheimer-type dementia

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Longitudinal, non-randomized one-way partial crossover | Age: | 78.3 | | Alzheimer-type dementia | Physical problems, medication | AD: | DSM IV NINCDS-ADRDA brain CT
Country: | Japan | %Male: | 43% | | | | PD:
Setting: | nd | Race: | Japanese | | | | VascDz:
Funding: | nd | Other: | | | | | Other:
Comments: Unclear how those getting Vit B12 were chosen. All received bright light × 4 wk, then half given B12 in addition to bright light. Analysis done on half at 4 wk and on other half with vit B12 + 8 wk bright light

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Bright light therapy × 8 wk + B12 1.5 mg/d (wk 5–6), B12 3.0 mg/d (wk 7–8) | Bright light therapy × 8 wk | N enrolled: | 28 | 14 | | 14
| | N analyzed: | 28 | 14 | | 14
| | Drop-outs (%):
Follow-up duration: 4 wk on B12 | | Reasons for drop out: No data reported on patients who were not treated with B12
Comments:

Primary outcome(s): | Clinical Dementia Rating (Hughes 1982; questionable 0.5 points, mild 1, moderate 2, severe 3) MMSE
Secondary outcome(s): | Sleep
Adverse events: | nd
Limitations: | Analyzed as an uncontrolled cohort
Quality (A/B/C): C | Applicability (1/2/3): 2

MMSE | | (0–30)
| | N | B12: All | 1.5–3 mg/d | N | B12: QMD** | 1.5–3 mg/d | N | B12: MSD** | 1.5–3 mg/d | N | Control
Baseline value | (SD) | | nd | | | | | | | | | nd
Final value | (SD) | 14 | 10.4 | 7.6 | | | | | | | 14 | 10.1 | 7.3
Difference
P Difference of Final values | | NS | | | NS | | | NS
Baseline value | (SD) | | | | | nd | | | | | | nd
Final value | (SD) | | | | 6 | 17.7 | 5.1 | | | | 6 | 17.3 | 4.5
Difference
P Difference of Final values | | | | | NS
Baseline value | (SD) | | | | | | | | nd | | | nd
Final value | (SD) | | | | | | | 8 | 4.9 | 2.9 | 8 | 4.8 | 2.7
Difference
P Difference of Final values | | | | | | | | NS

* Week 4 of study, when B12 was started

** Subsets: QMD: questionable (0.5 points) or mild (1 point) dementia; MSD: moderate (2 points) or severe (3 points) dementia.

Outcome(s): | Results (Text) (or Definition)
Clinical Dementia rating | No change with treatment
Sleep | Significantly less sleep during the day. No difference in sleep at night.

Intervention

Author, Year: Kwok, 1998 | Ref ID: 354 | Vitamins: B12
Objective: B12 supplementation of deficient patients on cognitive function

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | RCT | Age: | 76.6+/-6.8 | 77.4+/-6.4 | >60 yr and Serum B12 <120 pmol/L, vegetarians living at home or residence (majority of recruits) or non-vegetarians found to be B12 deficient as outpatient (minority of recruits). | Could not cooperate with neuropsychological tests because of severe confusion or communication problems; Hgb <9.0 g/dL, unstable medical condition, signs of combined degeneration of spinal cord | AD:
Country: | Hong Kong | %Male: | 4% | 0% | | | PD:
Setting: | Outpatient | Race: | nd | nd | | | VascDz:
Funding: | nd | Baseline B12 (nmol/L): | 87.3+/-24.0 | 77.9+/-27.8 | | | Dementia: | MMSE<20
Comments: randomization by HK ID card number (odd v even)

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Cobalamin 1 mg IM × 3 in wk 1, then 1 mg qWk × 3, then 1 mg qMo | No intervention | N enrolled: | nd | nd | | nd
| | N analyzed: | 50 | 23 | | 27
| | Drop-outs (%):
Follow-up duration: 3–6 months: B12 17.3+/-5.5 wk Control 16.1+/-3.2 wk | | Reasons for drop out:
Comments: Psychologists were blinded

Primary outcome(s): | Neuropsychological tests (including motor tests, not included here)
Secondary outcome(s):
Adverse events: | nd
Limitations: | Insufficient data about tests. Mix of 2 different populations.
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Definition
MMSE
Digit span | nd
WAIS-R | Defined as “similarities and block design subtests, and logical memory and visual reproduction subtests”. In Results, listed as Visual and Verbal memory, Verbal and Performance IQ.

WAIS-R, Wechsler Adult Intelligence Scale-Revised

Outcome | MMSE | (0–30)
| | N | B12 | | | | N | Control
Baseline value | (SD) | 27 | 22.2 | (4.7) | | | 23 | 23.8 | (4.7)
Final value | (SD) | 27 | 22.3 | (4.2) | | | 23 | 24.0 | (3.7)
Difference
P Difference | | NS | | | | | NS
Net Difference
P Net difference | | NS

Outcome | Visual Memory | (nd)
| | N | B12 | | | | N | Control
Baseline value | (SD) | 27 | 12.7 | 9.0 | | | 23 | 15.3 | 15.0
Final value | (SD) | 27 | 9.7 | 9.4 | | | 23 | 11.6 | 12.3
Difference
P Difference | | NS | | | | | NS
Net Difference
P Net difference | | NS

Outcome | Verbal Memory | | (nd)
| | N | B12 | | | | N | Control
Baseline value | (SD) | 27 | 7.8 | 6.1 | | | 23 | 11.4 | 6.8
Final value | (SD) | 27 | 6.7 | 5.9 | | | 23 | 9.3 | 6.2
Difference
P Difference | | NS | | | | | <0.05
Net Difference
P Net difference | | NS

Outcome | Digit Span | (nd)
| | N | B12 | | | | N | Control
Baseline value | (SD) | 27 | 10.4 | 3.8 | | | 23 | 11.6 | 3.5
Final value | (SD) | 27 | 10.7 | 3.6 | | | 23 | 10.6 | 2.9
Difference
P Difference | | NS | | | | | NS
Net Difference
P Net difference | | NS

Outcome | Verbal IQ | | (nd)
| | N | B12 | | | | N | Control
Baseline value | (SD) | 27 | 58.2 | 7.1 | | | 23 | 60.1 | 7.1
Final value | (SD) | 27 | 59.3 | 6.4 | | | 23 | 58.9 | 7.1
Difference
P Difference | | NS | | | | | NS
Net Difference
P Net difference | | NS

Outcome | Performance IQ | (nd)
| | N | B12 | | | | N | Control
Baseline value | (SD) | 27 | 74.9* | 13.1 | | | 23 | 84.3 | 15.3
Final value | (SD) | 27 | 80.7 | 12.0 | | | 23 | 85.8 | 16.7
Difference
P Difference | | <0.005 | | | | | NS
Net Difference
P Net difference | | NS

* Significant difference between intervention and control group at baseline.

When demented patients (n= 7 B12, 3 Control; Diagnosed by psychogeriatrician or MMSE<20), no difference in cognitive test results.

Among the 7 demented subjects who received cobalamin,

1 improved on the MMSE from 18 to 21, digit span, verbal memory, and performance IQ

1 improved on the MMSE from 19 to 24, verbal IQ, and performance IQ

1 improved on the MMSE from 5 to 9, and verbal memory

4 showed no “significant” improvement

None improved on visual memory test.

Intervention

Author, Year: Lehmann, 2003 | Ref ID: 1820 | Vitamins: B6/B12/Folate
Objective: Effect of multi-B vitamin on cognition and CSF-tau in mildly cognitively impaired

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Prospective cohort | Age: | 72 (59–81) | | Ambulatory, complaining of cognitive disturbances, MMSE 24–30, Serum Hcy >13.5nmol/L | Serum Cr >120 μmol/L, treatment with a cholinesterase inhibitor | AD:
Country: | Sweden | %Male: | 57% | | | | PD:
Setting: | Memory unit | Race: | nd | | | | VascDz:
Funding: | Pharmaceutical | Other: | | | | | Other:
Comments:

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Vit B12 1 mg po BID Folate 5 mg po BID Pyridoxine 40 mg po BID | | N enrolled: | 30 | 30 | | 0
| | N analyzed: | 30 | 30
| | Drop-outs (%):
Follow-up duration: Mean 270 (110–740) days | | Reasons for drop out:
Comments:

Primary outcome(s): | MMSE, CSF-tau
Secondary outcome(s): | CSF Albumin rati:, serum Hcy, B12, folate
Adverse events: | nd
Limitations:
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text) (or Definition)
MMSE
CSF-tau | sandwich ELISA with Innotest hTAU-Ag, measuring both normal and hyperphosphorylated tau

Outcome | MMSE | (0–30)
| | N | B6/B12/Folate | 2/10/80 mg | | | N | Control
Baseline value | (SD) | 30 | 26.3 | (1.8)
Final value | (SD) | 30 | 26.4 | (2.4)
Difference
P Difference | | NS
Net Difference | (SE/SD/95% CI)
P Net difference

Outcome | CSF-tau | | pg/mL
| | N | B6/B12/Folate | 2/10/80 mg | | | N | Control
Baseline value | (SD) | 30 | 529 | (242)
Final value | (SD) | 30 | 490 | (240)
Difference
P Difference | | NS
Net Difference | (SE/SD/95% CI)
P Net difference

At baseline CSF-tau was “considerably increased” compared to a non-cognitively impaired control group (222+/-92 pg/mL, n=35).

Intervention

Author, Year: Martin, 1992 | Ref ID: 10009 | Vitamins: Cobalamin
Objective: Cognitive effects of cobalamin replacement in patients suffering from cognitive impairment and low serum cobalamin levels

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Cohort | Age: | 79 | | Consecutive enrollment of cognitive impaired, serum cobalamin < 150 pmol/L | ND | AD:
Country: | USA | %Male: | 22 | | | | PD:
Setting: | Outpatient geriatric centers, inpt geropsychiatry unit, tertiary care university hospital | Race: | ND | | | | VascDz:
Funding: | Government | Other: | | | | | Other:
Comments:

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
1000 mcg cyanocobalamin intramuscular 1 at day for 1 wk, weekly for 1 mo, monthly ≥ 6 mo | | N enrolled: | 22
| | N analyzed: | 18
| | Drop-outs (%): | 4
Follow-up duration: Reasons for drop out: | | Died (2), unable to test due to: dementia (1), deafness (1)
Comments: Potential confounders: 3 Pts w/concomitant low serum folate also received oral folate replacement 1 mg @ day, 1 pt on tricyclic antidepressant at start of study, 4 pts on tricyclic antidepressant but was not new change in regimen

Primary outcome(s): | Changes in DRS scores pre vs post therapy
Secondary outcome(s): | Comparison of DRS scores by short vs long pretreatment symptom duration
Adverse events: | nd
Limitations:
Quality (A/B/C): C | Applicability (1/2/3): 1

Outcome(s): | Definition
Mattis DRS | Mattis Dementia Rating Scale. Used to evaluate pre & post therapy(≥ 6 mo), pts referred by primary physicians. DRS is 144 point mental status test with following criteria: mild impaired - 120–134, moderately impaired 90–119, severely impaired ≤ 90

Outcome(s): | Results
DRS scores | 11/18 improved (61%)

Outcome | DRS | Short duration symptoms | | | Long duration symptoms
| | N | Cobalamin | 1000 mcg | N | Cobalamin | 1000 mcg
Baseline value | (SD) | 5 | 108 (10) | | 13 | 108 (19)
Final value | (SD) | | 128 (13) | | | 105 (22)
Difference | (SE/SD/95% CI) | P = .0076 | | | P = 0.34
P Difference
Net Difference | (SE/SD/95% CI)
P Net difference
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

Intervention

Author, Year: McGeer, 1972 | Ref ID: 2107 | Vitamins: Folic acid
Objective: Effect of folate on PD

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Cohort (design unclear) | Age: | nd | | Parkinsonian patients | | AD:
Country: | Canada | %Male: | nd | | | | PD: | nd
Setting: | Clinic | Race: | nd | | | | VascDz:
Funding: | nd | Other: | | | | | Other:
Comments:

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Folic acid 15 mg qD | | N enrolled: | nd
| | N analyzed: | 18 | 18
| | Drop-outs (%):
Follow-up duration: Mean 45 (14–182) | | Reasons for drop out:
Comments:

Primary outcome(s): | Therapeutic benefit
Secondary outcome(s):
Adverse events: | “Only 3 patients reported any adverse effects. One experienced a buzzing in the ears, another a jittery feeling, and a third sleeplessness.” No mental changes, weight loss, or gastrointestinal symptoms.
Limitations:
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text) (or Definition)
Therapeutic benefit | 6: No therapeutic benefit
| 11: A slight subjective benefit (without appreciable objective change)
| 1: Worsening of gait.

Intervention

Author, Year: Meador, 1993 | Ref ID: 2127 | Vitamins: B1
Objective: The effect of 3–8 mg/d of thiamine in patients with Alzheimer's disease

2 Studies

Study 1

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | Randomized cross-over | Age: | 71 (61–86) | Meeting standard criteria for probable diagnosis of AD. All patients were living with devoted caretaker | h/o alcohol, drug abuse, lab evidence of malnutrition, medications for CNS activity. | AD: | Hachinski score ≤4
Country: | US | %Male: | 28% | | | PD:
Setting: | Free-living | Race: | nd | | | VascDz:
Funding: | Government | Other: | | | | Other:
Comments: A double blind placebo controlled cross-over trial with no wash out period

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Thiamine 3 g/d | Placebo | N enrolled: | 18 | 18 | | 18
| | N analyzed: | | 13–17 | | 13–17
| | Drop-outs (%):
Follow-up duration: 1 mo | | Reasons for drop out: ND
Comments:

Primary outcome(s): | Mean Alzheimer's Disease Assessment scale score;; Mini-mental status exam
Secondary outcome(s): | Single fiber EMG; The Clinical Global Impression of change (Physician rating of change from baseline)
Adverse events: | No adverse effects were noted
Limitations: | Small N, Poor reporting
Quality (A/B/C): C | Applicability (1/2/3): 2

ADAS | | 0–120 (higher score = poorer performance)
| | N | Thiamine | 3g/d | N | Placebo
Baseline value | (SD) | 17 | 36 | 25 | 17 | 36 | 25
Final value | (SD) | 17 | 41 | 27 | 17 | 44 | 28
Difference | (SE/SD/95% CI) | +2.1* | | | +6.7
P Difference | | nd | | | nd
Net Difference | (SE/SD/95% CI)
P Net difference | | nd

* These numbers are from text. Unclear why they do not correspond to reported data.

MMSE | | 0–30
| | N | Thiamine | 3 g/d | N | Control
Baseline value | (SD) | 17 | 18 | 7 | 17 | 18 | 7
Final value | (SD) | 17 | 18 | 7 | 17 | 17 | 7
Difference | (SE/SD/95% CI) | 0 | | | -1
P Difference | | NS | | | ND
Net Difference | (SE/SD/95% CI) | +1
P Net difference | | nd

Text:

ADAS scores better in thiamine period than control in 13/17 subjects (P=0.02)

ADAS on thiamine worse than baseline in 9/16 (NS)

ADAS on placebo worse than baseline in 12/16 (P=0.04)

Implicitly 1 patient each scored the same as at baseline during different periods.

MMSE scores were better in thiamine period than control in 6/8 (NS)

MMSE on thiamine worse than baseline in 9/13 (NS)

MMSE on placebo worse than baseline in 11/14 (P=0.03)

Implicitly 9 patients scored the same in both periods and 4 on thiamine and 3 on placebo scored the same as at baseline during different periods.

Study 2

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | Prospective, longitudinal cohort, with multiple one-way crossovers | Age: | 69 (54–93) | Meeting standard criteria for probable diagnosis of AD. All patients were living with devoted caretaker | h/o alcohol, drug abuse, lab evidence of malnutrition, medications for CNS activity. | AD: | Hachinski score ≤4
Country: | US | %Male: | 53% | | | PD:
Setting: | Free-living | Race: | nd | | | VascDz:
Funding: | Government | Other: | | | | Other:
Comments: 6 of the subjects also participated in the randomized cross-over study, with at least 3.5 months between trials.

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Thiamine, 4–6 g | Placebo | N enrolled: | 17 | 17 | | 17
| | N analyzed: | | 14–17* | | 13–15
| | Drop-outs (%):
Follow-up duration: 1 mo each at 4, 5, 6 g, and placebo | | Reasons for drop out: nd
Comments:

* Subsequent phases of trial included 2–13 subjects at “best dose” and between 6.5–8 g

Primary outcome(s): | Mean Alzheimer's Disease Assessment scale score;; Mini-mental status exam
Secondary outcome(s): | Single fiber EMG; The Clinical Global Impression of change (Physician rating of change from baseline)
Adverse events: | All tolerated doses up to 6 g/day well without any side effects. 2 (of 7) subjects reported nausea and indigestion at doses of 7.0 and 7.5 g/day but subsequently tolerated the same dosages in later months.
Limitations:
Quality (A/B/C): C | Applicability (1/2/3): 2

Phase 1: Open titration, from 4–6 g/day

ADAS | 0–120 | Month 1 | | | Month 4
| | N | Thiamine | 4 g | N | Placebo
Baseline value* | | 16 | 27.2 | | 13 | 26.2
Final value | | 16 | 23.4 | | 13 | 24.1
Difference
P Difference | | P≤0.01 | | | NS

ADAS | 0–120 | Month 2 | | | Month 4
| | N | Thiamine | 5 g | N | Placebo
Baseline value* | | 16 | 27.2 | | 13 | 26.2
Final value | | 16 | 23.7 | | 13 | 24.1
Difference
P Difference | | P≤0.055 | | | NS

ADAS | 0–120 | Month 3 | | | Month 4
| | N | Thiamine | 6 g | N | Placebo
Baseline value* | | 16 | 26.6 | | 13 | 26.2
Final value | | 16 | 24.3 | | 13 | 24.1
Difference
P Difference | | NS | | | NS

* Baseline means for subjects analyzed in each group.

MMSE | 0–30 | Month 1 | | | Month 4
| | N | Thiamine | 4 g | N | Placebo
Baseline value* | | 17 | 21.2 | | 15 | 21.5
Final value | | 17 | 21.7 | | 15 | 21.9
Difference
P Difference | | NS | | | NS

MMSE | 0–30 | Month 2 | | | Month 4
| | N | Thiamine | 5 g | N | Placebo
Baseline value* | | 17 | 21.2 | | 15 | 21.5
Final value | | 17 | 21.8 | | 15 | 21.9
Difference
P Difference | | NS | | | NS

MMSE | 0–30 | Month 3 | | | Month 4
| | N | Thiamine | 6 g | N | Placebo
Baseline value* | | 15 | 21.2 | | 15 | 21.5
Final value | | 15 | 21.7 | | 15 | 21.9
Difference
P Difference | | NS | | | NS

* Baseline means for subjects analyzed in each group.

Text:

In a month of best dose (month 5) ADAS and MMSE, difference compared to baseline was non-significant (n=13 & 15, respectively).

In months at 6.5 and 7 g/day (months 6,7) ADAS significantly better compared to baseline (P≤0.015 & P≤0.002, respectively; n=6).

In months with dose varying from 6.5–8 g/day (months 8, 9, 11, 13) ADAS no different than baseline (n=2–6).

MMSE were unchanged throughout the remainder of the study in 2–7 subjects.

Intervention

Author, Year: Mimori, 1996 | Ref ID: 2176 | Vitamins: Thiamine
Objective: To examine the beneficial effect of fursultiamine, in patients using a battery of tests of cognitive function

Study characteristics | | Population | | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Open non-comparative trial | Age: | 71.8±6.3 | | All outpatients who met the DSM-III/R criteria for dementia and the National Institute of Neurological and Communicative Disorders and Stroke-Alzheimer's Disease and Related Disorders Association (NINCDS-ADRDA) | ND | AD: | Same as inclusion criteria
Country: | Japan | %Male: | 44% | | | | PD: | NA
Setting: | University hospital | Race: | 100% Asian | | | | VascDz: | NA
Funding: | Private | Other: | Mean duration of illness: 2.3±1.4 yr | | | | Other: | NA
Comments: Fursultiamine (thiamine tetrahydrofurfuryl disulfide hydrochloride (TTFD) a derivative of thiamine which is easily converted into the active form of thiamine in the body

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Fursultiamine 100 mg/d in 2 divided doses | NA | N enrolled: | 9 | 8 | NA | NA
| | N analyzed: | 9 | 9
| | Drop-outs (%): | 11% (1/9)
Follow-up duration: 12 wk | | Reasons for drop out: Family commitments
Comments: 1 patient that did not complete the study was included in the analysis Thiamine measured using HPLC method

Primary outcome(s): | Hasegawa Dementia Scale (HDS) | Total score 32.5 (higher score indicates better performance). Widely used in as screening tests of cognitive function in Japan along with MMSE
Primary outcome(s): | Mini-Mental State Examination (MMSE) | Total score 30 (higher score indicates better performance)
Primary outcome(s): | Rating scale by Gottfries (Modified GBS) | Total score 228 (lower score indicates better function) Assesses intellectual function, spontaneity, emotional function, motor function, and other symptoms of dementia
Secondary outcome(s): | Blood level of thiamine
Adverse events: | All patients tolerated the drug and dosages well
Limitations: | Small sample size
Quality (A/B/C): C | Applicability (1/2/3): 1

Outcome(s): | Results (Text) (or Definition)
Blood level of thiamine | Baseline Mean blood level of thiamine: 32.5±11.3 (19.5 to 49.3 ng/mL and within normal limits. Among patients with relatively low thiamine levels 1 patient showed some improvement and 1 did not. Blood thiamine levels increased markedly after TTFD administration (257.4±99.4 ng/mL)

HDS | Hasegawa Dementia Scale | | 0–32.5
| | N | Fursultiamine | 100 mg/d in 2 divided doses
Baseline value | (SD) | 9 | 17.0 | (9.7)
Final value | (SD) | 9 | 17.6 | (10.4)
Difference | (SD) | 0.6 | | (0.7)
P Difference | | NS
Net Difference | (SE/SD/95% CI)
P Net difference
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

MMSE | Mini-Mental State Exam | 0–30
| | N | Fursultiamine | 100 mg/d in 2 divided doses
Baseline value | (SD) | 9 | 17.2 | (7.0)
Final value | (SD) | 9 | 19.4 | (9.0)
Difference | (SD) | 2.2 | | (2.0)
P Difference | | <0.05
Net Difference | (SE/SD/95% CI)
P Net difference
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

Total GBS | Gottfries (Modified GBS) | 0–228
| | N | Fursultiamine | 100 mg/d in 2 divided doses
Baseline value | (SD) | 9 | 59.8 | (38.5)
Final value | (SD) | 9 | 52.4 | (41.8)
Difference | (SD) | -7.4 | | (3.3)
P Difference | | <0.1(NS)
Net Difference | (SE/SD/95% CI)
P Net difference
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

Intervention

Author, Year: Mitsuyama, 1988 | Ref ID: 2185 | Vitamins: B12
Objective: To examine the effect of CH3-B12 on the CNS and clinical effectiveness for organic mental symptoms. To determine the correlation between the serum vitB12 and CSF vitB12

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Non comparative open trial and correlational study | Age: | 53±3.1 (34–77) | | Subjects who fulfilled the clinical criteria of dementia. Confirmed in all patients by the finding of cerebral atrophy and widening of the ventricles on the CT scan. | Any disorder known to affect vit B12 metabolism, such as acute physical disease, malnutrition, severe anemia, and myeloproliferative disorders and abnormal kidney and liver disorders | AD: | Same as inclusion criteria
Country: | Japan | %Male: | 64% | | | | PD: | NA
Setting: | Academic hospital | Race: | 100% Asian | | | | VascDz: | NA
Funding: | ND | Other: | | | | | Other: | Pick's disease
Comments: 4 patients were mildly demented; 7 moderately demented; 3 patients were severely demented

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Vit B12 2mg/d for 60d | None | N enrolled: | 14 | 5 | 9
Vit B12 2 mg/d PO and 500μg/d IM | | N analyzed: | 14 | 5 | 9
| | Drop-outs (%): | 0
Follow-up duration: 60 days | | Reasons for drop out: NA
Comments: Sr and CSF B12 assessed by radioassay range between 25 to 1600 pg/mL

Primary outcome(s): | Change in GBS scale (a neuropsychological scale developed by Gottfries) | Correlation between serum and CSF vit B12
Secondary outcome(s): | Correlation of sr and CSF-VB 12 with severity of dementia
Adverse events: | ND
Limitations: | Small sample size (only 1 patient with AD and W-K); 1 patient had unclassified presenile dementia; all mostly had pick's disease
Quality (A/B/C): B (comparative trial and small sample size) | Applicability (1/2/3): 2 Broad range of dementia

Outcome(s): | Results (Text) (or Definition)
Correlation of Serum and CSF Vit B12 with severity of dementia | No correlation between the concentration of serum and CSF vit B12 levels and severity of dementia without B12 administration
Change in GBS scale | No change in GBS scale with administration of CH3-B12. However patients on both PO and IM reported improvement in mood and social behavioral changes and enhanced self rating of competencies

Intervention

Author, Year: Nilsson, 2000 | Ref ID: 2338 | Vitamins: B12
Objective: A study on dementia patients with specific aim to investigate the relation between B12 deficiency, clinical changes and cerebral blood flow

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Non-randomized trial | Age: | 79.8 (6.2) | No controls | Patients selected from consecutive admissions to the psychogeriatric department and those with low serum cobalamin level (155 pmol/L) detected during the diagnostic examination were included | Those with acute or unstable physical conditions and recent cerebrovascular accidents | AD: with late onset | NINCDS-ADRDA criteria and classified according to DSM-III-R as mild, moderate or severe
Country: | Sweden | %Male: | 50% | | | | PD:
Setting: | University hospital | Race: | Probably white | | | | VascDz: | Criteria of NINDS-AIREN for vascular dementia with no major strokes
Funding: | Private foundation-Non Industry | Other: | | | | | Other: | Mixed and vascular dementia
Comments:

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Hydroxycobalamin 1 mg every second day × 10 times and thereafter 1 mg/month | None | N enrolled: | 29 | 24
| | N analyzed: | 24 | 24
| | Drop-outs (%): | ND
Follow-up duration: 1 month / 1 wk for MMSE | | Reasons for drop out:
Comments: Final data includes both vasc dementia, AD and mixed dementia

Sr cobalamin determined using radioassay and reference limit 110–650 pmol/L and 155 pmol/L as the lower reference limit for cobalamin

Primary outcome(s): | Clinical improvement; MMSE score improvement; Cerebral blood flow
Secondary outcome(s): | Hcy, MMA
Adverse events: | ND
Limitations: | Includes patients with delirium. Delirium could be secondary to dementia and as due to cobalamin deficiency; consecutive patient enrollment
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text) (or Definition)
Clinical improvement | The 15 patients who responded to cobalamin treatment were judged to be demented to about the same degree as before treatment, although behavioral symptoms diminished. The improved group had mild to moderate dementia at baseline
Cerebral blood flow | The improved group of patients (n=15) had a significant higher value compared to baseline after 1 month.
| The group of patients with no or little clinical improvement showed non significant decrease after 1 month
Regional cerebral blood flow | There was no significant difference in the rCBF pattern between clinically improved and non-improved cases at baseline.
| The clinically improved patients showed a general flow increase and regional central temporal blood flow increase compared to baseline (p<0.05)
| The non responders to cobalamin treatment showed a flow increase in primarily sensory motor areas after 1 month (p<0.03) and more pronounced central lobe rCBF increase after a longer period of treatment than did the clinically improved group
MMSE | Only 10 patients tested at 1 week, 2 AD, 3 mixed AD+vascular (5 vascular). No further extraction performed

Intervention

Author, Year: Nilsson, 2001 | Ref ID: 2340 | Vitamins: B12, folate
Objective: To investigate the effect of B12, folate supplementation on cognitive function in elderly patients with demtentia

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Non-controlled trial | Age: | 78.4 ±8.1 | N/A | Consecutive patients with symptoms of organic brain disease referred to a University Hospital for Dx examination and Tx | Patients with acute or unstable conditions, with non-organic psychiatric disease, with ongoing Vit substitution | AD:8 | See criteria for Other and VascDz
Country: | Sweden | %Male: | 42 | N/A | | | PD:
Setting: | University Hospital outpatients | Race: | ND | N/A | | | VascDz: 19 | Severity of dementia was assessed by DSM III-R Clinical Dx based on psychiatric, neurological, physical, and laboratory investigations, psychometric testing, measurement of regional cerebral blood flow (Risberg 1980), EEG, CT or MRI
Funding: | Government non-profit | Other: | | | | | Other: Fronto-temporal dementia: 1; mixed AD with VascDz: 1; other specified: 2; non-specified: 2
Comments:

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
B12 per os 1mg/d | N/A | N enrolled: | 33 | | | N/A
Folate per os 5mg/d | | N analyzed: | 28 | | | N/A
| | Drop-outs (%): | 5 (15)
Follow-up duration: 2 mo | | Reasons for drop out: Severely demented patients who could not cooperate in the tests before or after the Tx
Comments:

Primary outcome(s): | MMSE, SKT scores, GI
Secondary outcome(s):
Adverse events: | ND
Limitations: | Small sample size (especially for Hcy subgroups)
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text) (or Definition)
MMSE | Total score may vary between 0 and 30, with lower scores indicating severe cognitive impairment
SKT | Short cognitive performance test for assessing memory and attention in the sense of info processing speed; consists of 9 subtests (each limited to a max time 60 sec; total score varies between 0 to 27; higher scores indicate more severe cognitive impairment
Global impression of change (GI) | It was made and documented by an experienced clinician according to a standardized clinical assessment and by interviews with relatives and caregivers. The patients were classified as globally improved (GI score=1) following supplementation when clinician and caregivers /relatives reported improvements in alertness, orientation in time and space, recent memory and fewer clinical fluctuations. Patients who did not improve were classified as unchanged (GI score=0) Among patients with normal Hcy 2/11 improved while among patients with increased Hcy 14/17 improved

Patients with normal Hcy

MMSE | | Score
| | N | B12 | 1mg/d | N | Folate | 5mg/d | N | (Intervention) | (Dose) | N | Control
Baseline value | (SE/SD) | 11 | 21.3 | 4.9 | 11 | 21.3 | 4.9 | | | | N/A | N/A | N/A
Final value | (SE/SD) | 11 | 20.9 | 4.7 | 11 | 20.9 | 4.7 | | | | N/A | N/A | N/A
Difference | (SE/SD/95% CI) | -0.4 | | ND | -0.4 | | ND | | | | N/A | | N/A
P Difference | | NS | | | NS | | | | | | N/A
Net Difference | (SE/SD/95% CI)
P Net difference
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

Serum B12 and blood folate concentration were determined by immunoassay using purified intrinsic factor and purified folate binding protein (Vit B12/folate kit; Amersham, UK). The reference intervals for B12 are 110–650 pmol/L and for folate 125–500 nmol/L

Unclear whether SD or SE is reported

Patients with increased Hcy

MMSE | | Score
| | N | B12 | 1mg/d | N | folate | 5mg/d | N | (Intervention) | (Dose) | N | Control
Baseline value | (SE/SD) | 17 | 17.2 | 8.3 | 17 | 17.2 | 8.3 | | | | N/A | N/A | N/A
Final value | (SE/SD) | 17 | 21.4 | 4.7 | 17 | 21.4 | 4.7 | | | | N/A | N/A | N/A
Difference | (SE/SD/95% CI) | +4.2 | | ND | +4.2 | | ND | | | | N/A | | N/A
P Difference | | <0.01 | | | <0.01 | | | | | | N/A
Net Difference | (SE/SD/95% CI)
P Net difference
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

Serum B12 and blood folate concentration were determined by immunoassay using purified intrinsic factor and purified folate binding protein (Vit B12/folate kit; Amersham, UK). The reference intervals for B12 are 110–650 pmol/L and for folate 125–500 nmol/L

Unclear whether SD or SE is reported

Patients with normal Hcy

SKT | | Score
| | N | B12 | 1mg/d | N | Folate | 5mg/d | N | (Intervention) | (Dose) | N | Control
Baseline value | (SE/SD) | 11 | 15.6 | 4.5 | 11 | 15.6 | 4.5 | | | | N/A | N/A | N/A
Final value | (SE/SD) | 11 | 14.8 | 4.9 | 11 | 14.8 | 4.9 | | | | N/A | N/A | N/A
Difference | (SE/SD/95% CI) | -0.8 | | ND | -0.8 | | ND | | | | N/A | | N/A
P Difference | | NS | | | NS | | | | | | N/A
Net Difference | (SE/SD/95% CI)
P Net difference
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

Serum B12 and blood folate concentration were determined by immunoassay using purified intrinsic factor and purified folate binding protein (Vit B12/folate kit; Amersham, UK). The reference intervals for B12 are 110–650 pmol/L and for folate 125–500 nmol/L

Unclear whether SD or SE is reported

Patients with increased Hcy

SKT | | Score
| | N | B12 | 1mg/d | N | Folate | 5mg/d | N | (Intervention) | (Dose) | N | Control
Baseline value | (SE/SD) | 17 | 18.5 | 5.5 | 17 | 18.5 | 5.5 | | | | N/A | N/A | N/A
Final value | (SE/SD) | 17 | 14.6 | 4.35 | 17 | 14.6 | 4.35 | | | | N/A | N/A | N/A
Difference | (SE/SD/95% CI) | -3.9 | | ND | -3.9 | | ND | | | | N/A | | N/A
P Difference | | <0.01 | | | <0.01 | | | | | | N/A
Net Difference | (SE/SD/95% CI)
P Net difference
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

Serum B12 and blood folate concentration were determined by immunoassay using purified intrinsic factor and purified folate binding protein (Vit B12/folate kit; Amersham, UK). The reference intervals for B12 are 110–650 pmol/L and for folate 125–500 nmol/L

Unclear whether SD or SE is reported

Intervention

Author, Year: Nolan, 1991 | Ref ID: 2360 | Vitamins: B1
Objective: To determine efficacy of B1 supplementation on cognitive function tests

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | RCT (Double-blind) | Age: | Total (N=15) mean 76.3 Range 59–87 | | Patients from geriatric Evaluation Service (sub-specialty clinic) who had clinical Dx of probable or possible AD | ND | AD: | Probable or possible AD as defined by the NINCDS-ADRDA criteria (REF 9 in the paper)
Country: | US | %Male: | Total (N=15) 33 | | | | PD:
Setting: | Nursing home and outpatient clinic | Race: | ND | ND | | | VascDz:
Funding: | Government/non-profit | Other: | | | | | Other:
Comments: Population characteristics are not given separately for the 2 comparative groups

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
B1 (HCL) as caps of 1g each | Placebo: lactose (Caps of the same appearance, size, and weight as intervention) | N enrolled: | 15 | ND
Dose 3g/d (3 capsules) | | N analyzed: | 10 | 5 | | 5
| | Drop-outs (%): | 5 (33) | 8 (14)
Follow-up duration: 12 months | | Reasons for drop out: Poor compliance: 3; health problems unrelated to intervention: 2; 1: protocol violation
Comments: An additional analysis was performed including 2 patients who had complete data only for 9 mo (Total N: 12; 6 intervention - 6 control)

Primary outcome(s): | MMSE
Secondary outcome(s): | Verbal fluency, short (15-item) Boston naming test; constructional praxis test; 10-item word list learning test; tests of recall and recognition
Adverse events: | ND
Limitations: | Small sample size; randomization method not described; power calculation not reported; intention-to-treat analysis not accurately applied; relatively high drop-out rate (33%)
Quality (A/B/C): C | Applicability (1/2/3): 1

Outcome(s): | Results (Text) (or Definition)
CERAD | Patients were seen at 3-mo intervals The CERAD (Consortium to Establish a Registry for AD) neuropsychological battery was administered to each patient by the same examiner at each visit, including the baseline visit. This battery includes the instruments referred as primary and secondary outcomes above: Verbal fluency, Short (15-item) Boston naming test, MMSE, Constructional praxis test, 10-item word list learning test, Recall and Recognition tests
Verbal fluency | Verbal learning scores at 12 mo were significantly lower than those at 3 mo and baseline (p<0.05). When 12 patients included in analyses (follow-up: 9 mo), the verbal learning scores at 9 mo were significantly lower than those at all other observations (p<0.05).
Short (15-item) Boston naming test | Mean naming scores at 12 mo were significantly lower than those at all other observations (p<0.05). The mean MMSE scores at 6 mo were significantly lower than those at all earlier observations (p<0.05)
MMSE | A 2-way (group × time) repeated ANOVA measures obtained at the 5 clinic visits indicated NS difference between the comparative groups. The mean MMSE score at mo 3, 6, 9, 12 were significantly lower than baseline (p<0.05). The mean MMSE scores at 12 mo were significantly lower than those at all other observations (p<0.05). The mean MMSE scores at 9 mo were significantly lower than those at all earlier observations (p<0.05). When 12 patients included in analyses (follow-up: 9 mo), the mean MMSE scores at 12 mo were significantly lower than those at all other observations (p<0.05).
Constructional praxis test | NS difference between groups
10-item word list learning test | Verbal learning scores at 12 mo were significantly lower than those at 3 mo and baseline (p<0.05).
Recall test | Delayed recall scores were not formally analyzed, due to floor effects; only 3 /10subjects were ever able to recall more than 1 item from the 10-word lists, and the most frequent score was 0.
Recognition test | Delayed recognition scores between groups, NS.

All Subjects

Outcome | MMSE | ND
| | N | B1 | 3g/d | N | (Intervention) | (Dose) | N | (Intervention) | (Dose) | N | Control
Baseline value | (SE/SD) | 5 | 16.6 | 5.73 | | | | | | | 5 | 16 | 5.7
Final value | (SE/SD) | 5 | 10.4 | 9.13 | | | | | | | 5 | 14.6 | 7.09
Difference | (SE/SD/95% CI) | -6.2 | | <0.05 | | | | | | | -1.4 | | <0.05
P Difference | | ND | | | | | | | | | ND
Net Difference | (SE/SD/95% CI) | -4.8 | | ND
P Net difference | | ND

Intervention

Author, Year: Rapin, 1988 | Ref ID: 10015 | Vitamins: Folate
Objective: Effect of folate treatment on cognitive function

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | Prospective single cohort | Age: | 62+/-5 | RBC folate<300 ng/mL. “All patients have memory disorders with fatigability and disinterest for life.” | Megaloblastic marrow and organic diseases. | AD: | nd
Country: | France | %Male: | nd | | | PD:
Setting: | nd | Race: | nd | | | VascDz:
Funding: | nd | Other: | | | | Other:
Comments:

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Folinic acid, 50 mg/week po | (none) | N enrolled: | | nd
| | N analyzed: | | 38
| | Drop-outs (%):
Follow-up duration: 120 days | | Reasons for drop out:
Comments:

Primary outcome(s): | 16 scales that are either not defined or poorly defined.
Other outcome(s): | Depression scale
Adverse events: | nd
Limitations: | Very poor reporting
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Definition
PRM 4 from Rey | nd
PRM 6 from Rey | analyzes different stages of memorization visuo verbal, learning capacity, immediate and delayed recall
Benton's VRT | evaluates visuo-spatial memory
3 words of Luria | analyzes verbal interferences
Porteus maze | gives an assessment of perception and visuo-spatial organization
Reaction time test, visual | gives an assessment of psychomotor coordination ability
Reaction time test, auditory | gives an assessment of psychomotor coordination ability
Reaction time test, mixed | gives an assessment of psychomotor coordination ability
PRM 7 from Rey | nd
Video coupled object test | measures associative memory
15 words of Rey | Verbal learning tests
Daily activities test | nd
Compound series of Morisby | evaluates logical reasoning
Porteus maze delayed | studies recall of visuo spatial memory
Video coupled object, delayed | no specific definition
Overlapped drawing by Rey | measures perception and ability to discriminate the figures

Results are displayed graphically, measured as % of deficit compared to separately analyzed age-matched healthy individuals.

Outcome(s): | Results
Cognitive tests | There were significant improvements in the following tests: Benton's VRT; Porteus maze; Video coupled object test; Daily activities test; Compound series of Morisby.
| Other tests showed no difference from baseline to 120 days of treatment.

Intervention

Author, Year: Seal, 2002 | Ref ID: 10017 | Vitamins: B12
Objective: B12 supplementation in elderly. Determination of minimum dose to restore normal serum B12

Study characteristics | | Population | | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | RCT | Age: | 82.0 | 84.9 | 77.6 | Resident in geriatric center or extended care facility, subnormal serum B12 (between 100–150 pmol/L) | None had a previous history of gastric or bowel surgery or symptoms to suggest malabsorption. Known neoplasm, terminal illness, history or diagnosis of malabsorption, pernicious anemia or other anemia, prior B12 or vitamin supplementation. | AD:
Country: | Australia | %Male: | 40% | 50% | 45% | | | PD:
Setting: | Geriatric center | Race: | nd | nd | nd | | | VascDz:
Funding: | Hospital | Other: | ~1/3 had dementia (not defined); ~1/2 had cerebrovascular or cardiovascular disease | | | | | Other:
Comments: Double blind

Intervention(s): | Control: | | Total | B12 10 μg | B12 50 μg | Control
Vitamin B12 50 μg daily | Placebo | N enrolled: | | 10 | 10 | 11
Vitamin B12 50 μg daily | | N analyzed: | | 9 | 10 | 8
| | Drop-outs (%): | 0
Follow-up duration: ~4 wk (mean 31 days, range 27–39) | | Reasons for drop out:
Comments:

Primary outcome(s): | Serum B12
Secondary outcome(s): | Mini Mental Status Exam (MMSE), folate, homocysteine, hemoglobin, mean corpuscular volume
Adverse events: | nd
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 1

Outcome(s): | Results (Text) (or Definition)

(Separate table for each outcome)

Outcome | MMSE | (0–30)
| | N | B12 | 10 μg | N | B12 | 50 μg | | N | Placebo
Baseline value* | (SD) | 9 | 15.4 | (7.8) | 10 | 19.7 | (5.3) | | 8 | 19.6 | (6.3)
Final value | | 9 | | | 9 | | | | 8
Difference | (SD) | | 0 | (2.9) | | +1 | (3.2) | | | +1.6 | (2.1)
P Difference | | NS (0.49)**
Net Difference | (SE/SD/95% CI)
P Net difference

* Baseline values not significantly different from each other.

** ANOVA, comparing all 3 groups simultaneously.

Intervention

Author, Year: Sommer, 2003 | Ref ID: 3063 | Vitamins: Folic acid
Objective: Folate supplementation for dementia

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | RCT | Age: | 77 (68–80) | Age ≥65 yr, Dementia (DSM-III R), serum folate 2–5 μg/L, RBC folate 127–452 μg/L, B12>200 ng/L. (Refrained from vitamin supplementation for at least 1 mo prior to study.) | Seizure disorder, major depression or need for antidepressant medication | AD:
Country: | US | %Male: | 57% | | | PD:
Setting: | Community | Race: | nd | | | VascDz:
Funding: | nd | Other: | | | | Dementia: | DSM-III-R
Comments: Dx: Probable AD, 3; Dementia not otherwise specified, 2; Lewy body dementia, 1; vascular dementia, 1 Baseline MMSE: mean 20.4 (range 14–27)

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Folic acid 10 mg BID | Placebo | N enrolled: | 11 | 5 | | 6
| | N analyzed: | 7 | 4 | | 3
| | Drop-outs (%): | 36%
Follow-up duration: 10 wk | | Reasons for drop out: Tx: Dropped out (did not return calls); Cx: Care giver wanted NH care 1, nausea/diarrhea 1, scheduling difficulties 1
Comments: Double blind, pill counting performed. One of dropouts apparently described in wrong arm.

Primary outcome(s): | Language:
| WAIS-R: Pro-rated Verbal IQ | measure of intellectual function
| Boston Naming Test | object-naming, detect difficulties in confrontation naming
| Controlled Oral Word Association Test | verbal fluency
| Memory:
| Wechsler Memory Scale (WMS):Logical Memory Subtest | short-term vocabulary
| WMS: Associate Learning Subtest | short-term vocabulary
| Speed/Concentration:
| Trails A and B | visual scanning, conceptual flexibility, motor speed
| Finger Tapping Test | pure motor speed
Secondary outcome(s):
Adverse events: | “Safe and well-tolerated.”
Limitations: | 1/7 subjects with vascular dementia. Very small N. High dropout.
Quality (A/B/C): C | Applicability (1/2/3): 1

Outcome(s): | Results (Text) (or Definition)
All | The magnitude of change between baseline and second testing was not statistically significant for folic acid and placebo groups. There was a trend for the folic acid group to perform worse than the placebo group on the Associate Learning Subtest (P<0.08) and on Trails B (P<0.08), which suggest a trend toward a worsening of cognitive abilities secondary to the folic acid supplementation. Specifically, verbal memory and perceptual motor speed may have been negatively affected.

Outcome | | WAIS-R: Pro-rated Verbal IQ | | | (Normal mean = 100)
| | N | Folic acid | 20 mg | N | Control
Baseline value | (SD) | 4 | 107.8 | (12.8) | 3 | 110.0 | (24.9)
Final value | (SD) | 4 | 105.3 | (16.7) | 3 | 122.5 | (10.6)
Difference
P Difference
Net Difference
P Net difference | | 0.81

Outcome | | Boston Naming Test | | | (nd range)
| | N | Folic acid | 20 mg | N | Control
Baseline value | (SD) | 4 | 40.8 | (19.7) | 3 | 42.3 | (15.6)
Final value | (SD) | 4 | 42 | (22.7) | 3 | 43.7 | (12.4)
Difference
P Difference
Net Difference
P Net difference | | 0.86

Outcome | | Controlled Oral Word Association Test | | | (nd range)
| | N | Folic acid | 20 mg | N | Control
Baseline value | (SD) | 4 | 29.5 | (10.5) | 3 | 36.0 | (24.0)
Final value | (SD) | 4 | 32.8 | (14.9) | 3 | 31.0 | (27.7)
Difference
P Difference
Net Difference
P Net difference | | 0.48

Outcome | | Wechsler Memory Scale: Logical Memory Subtest | | | (nd range)
| | N | Folic acid | 20 mg | N | Control
Baseline value | (SD) | 4 | 4.9 | (2.0) | 3 | 4.6 | (5.1)
Final value | (SD) | 4 | 4.9 | (2.5) | 3 | 6.3 | (7.3)
Difference
P Difference
Net Difference
P Net difference | | 0.28

Outcome | | Wechsler Memory Scale: Associate Learning Subtest | | | (nd range)
| | N | Folic acid | 20 mg | N | Control
Baseline value | (SD) | 4 | 16.6 | (2.5) | 3 | 11.0 | (3.5)
Final value | (SD) | 4 | 9.5 | (3.0) | 3 | 11.3 | (5.3)
Difference
P Difference
Net Difference
P Net difference | | 0.08

Outcome | | Speed/Concentration: Trails A | | | (seconds, nd normal)
| | N | Folic acid | 20 mg | N | Control
Baseline value | (SD) | 4 | 233.0 | (249.3) | 3 | 277.7 | (320.5)
Final value | (SD) | 4 | 247.8 | (256.2) | 3 | 261.0 | (296.5)
Difference
P Difference
Net Difference
P Net difference | | 0.16

Outcome | | Speed/Concentration: Trails B | | | (seconds, nd normal)
| | N | Folic acid | 20 mg | N | Control
Baseline value | (SD) | 4 | 373.0 | (263.7) | 3 | 412.0 | (227.6)
Final value | (SD) | 4 | 393.3 | (239.3) | 3 | 257.3 | (269.1)
Difference
P Difference
Net Difference
P Net difference | | 0.08

Outcome | | Speed/Concentration: Finger Tapping Test | | | (nd range)
| | N | Folic acid | 20 mg | N | Control
Baseline value | (SD) | 4 | 38.4 | (9.2) | 3 | 32.7 | (9.5)
Final value | (SD) | 4 | 37.9 | (8.8) | 3 | 24.3 | (15.1)
Difference
P Difference
Net Difference
P Net difference | | 0.56

Intervention

Author, Year: Teunisse, 1996 | Ref ID: 3238 | Vitamins: B12
Objective: Effect of B12 repletion on dementia

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | Prospective longitudinal cohorts | Age: | 77.5+/-5.3 | Age ≥65 yr, suspected dementia by general practitioner. Diagnosis of dementia by DSM-III-R criteria. | Previous neurological, neuroradiological examination or extensive diagnostic laboratory investigation for the same complaints. Serious co-morbidity precluding follow-up | AD: | DSM-III-R
Country: | Netherlands | %Male: | 42% | Serum B12 <200 pg/L | | PD:
Setting: | Clinic | Race: | nd | | | VascDz:
Funding: | Government | Duration of symptoms: | 45+/-32 mo | | | Dementia: | DSM-III-R CAMDEX
| | B12 | 150 (35–195)
Comments: Study also evaluated a “reference group” of subjects with normal B12. This group not treated. Not included here.

Intervention(s): | Reference: | | Total | Intervention 1 | Intervention 2 | Control
Cobalamin | No treatment | N enrolled: | 108 | 26
1000 μg qD × 5 days, then qMo, or | | N analyzed: | | 19
1000 μg qWk × 5 days, then bi-monthly | | Drop-outs (%): | | 27%
Follow-up duration: Mean+/-SD: 214+/-64 days | | Reasons for drop out: 1 not treated as advised, 1 stroke, 2 died, 3 measurements not available. (2 also were not cooperative with CAMCOG).
Comments: All but 1 of 26 with subnormal B12 fulfilled criteria for possible AD (1 also had cerebral infarctions).

Primary outcome(s): | Cognitive impairment, disability in ADL, behavioral changes
Secondary outcome(s): | Caregiver burden
Adverse events: | nd
Limitations:
Quality (A/B/C): C | Applicability (1/2/3): 2

CAMDEX, Dutch version of the Cambridge Examination for Mental Disorders of the Elderly

Outcome(s): | Definition
CAMCOG | Subscale of CAMDEX, assesses orientation, language, memory, praxis, attention, abstract thinking, perception and calculation (includes MMSE)
IDDD | Interview for Deterioration in Daily living activities in Dementia, caregiver assessment of functioning in the past week; subscales for initiative and performance (assistance necessary)
RMBPC | Revised Memory and Behavioral Problems; 3 subscales for memory, depression (not included here), and disruptive behavior

B12 intervention | | Test | | Scale
| | N | CAMCOG | (0–106^*^) | N | IDDD-Init | (36–0^**^) | N | IDDD-Perf | (44–0^**^)
Baselinevalue | SD | 19 | 64.9 | 15.7 | 19 | 13.8 | 9.2 | 19 | 12.7 | 9.7
Final value | | 17 | | | 19 | | | 19
Difference ^ *** ^ | 95% CI | -1.4 | | -7.4, +4.6 | -4.9 | | -9.4, -0.4 | -7.8 | | -13.3, -2.3
P Difference | | NS | | | <0.05 | | | <0.05

B12 intervention | | Test | | Scale
| | N | MMSE | (0–30^*^) | N | RMBPC-Mem | (28–0^**^) | N | RMBPC-Dis | (32–0^**^)
Baselinevalue | SD | 19 | 17.5 | 7.2 | 19 | 17.5 | 5.0 | 19 | 4.4 | 4.6
Final value | | 17 | | | 19 | | | 19
Difference | 95% CI | -1.8 | | -3.5, -0.1 | -0.4 | | -3.5, +2.7 | -2.6 | | -4.8, -0.4
P Difference | | <0.05 | | | NS | | | <0.05

* High score reflects less deterioration

** High score reflects more deterioration

*** Negative scores reflect deterioration, positive scores reflect improvement.

Although not a true comparison to a control, compared to the reference group of 69 patients with dementia with normal serum B12 at baseline (who were not treated), no significant difference in degree of deterioration.

Intervention

Author, Year: van Asselt, 2001 | Ref ID: 10005 | Vitamins: B12
Objective: B12 for cognitive function in B12-deficient people

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | Prospective longitudinal cohort, Single cross-over with placebo | Age: | 71* (64–89) | Community-dwelling, “older,” plasma B12 ≤150 pmol/L | None had anemia, low serum or RBC folate, myelopathy, history of B12 deficiency, B12 or folate supplementation, severe diseases, or severe cognitive or sensory problems | AD:
Country: | Netherlands | %Male: | 44% | (One subject had an MMSE score of 23) | | PD:
Setting: | Community | Race: | nd | | | VascDz:
Funding: | Government | Other: | | | | Other:
Comments:

* Median

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Hydroxycobalamin 1mg weekly × 4, then monthly × 4 IM | Placebo (water injection, weekly × 4), prior to start of B12 treatment | N enrolled: | 16+2*
| | N analyzed: | 16 | 16 | 16
| | Drop-outs (%):
Follow-up duration: 1 mo Placebo, then 5 mo B12 | | Reasons for drop out: *
Comments:

* 16 enrolled. 2 dropped out (1 protocol burdensome, 1 died of lung cancer). In their place, 2 other eligible people agreed to participate.

Primary outcome(s): | Biochemical, EEG, and neuropsychological tests
Secondary outcome(s):
Adverse events: | nd
Limitations:
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Definition
MMSE | nd
WAIS Forward and Backward Digit Span | nd
Verbal Word Learning Test (immediate and delayed recall) | nd
Verbal Fluency | nd
Similarities | nd
Trail Making Test | nd
Rivermead Behavioral Face Recognition Test | nd
(Geriatric Depression Scale)

Outcome | | Verbal Word Learning Test (Delayed recall) | | | (nd on range)
| | N | B12 | | N | Placebo*
Baseline MEDIAN | (Range) | 16 | 6 | (1–11) | 16 | Same
Final MEDIAN | (Range) | 16 | 11 | (2–14) | 16 | 7 | (0–13)
Difference
P Difference | | NS | | | NS
NetDifference
P Net difference | | 0.03

* 1 month prior to B12 treatment

Outcome | | Verbal Fluency | | | (nd on range)
| | N | B12 | | N | Placebo*
Baseline MEDIAN | (Range) | 16 | 20 | (14–22) | 16 | Same
Final MEDIAN | (Range) | 16 | 18 | (9–22) | 16 | 15 | (7–22)
Difference
P Difference | | NS | | | 0.003
NetDifference
P Net difference | | 0.004

* 1 month prior to B12 treatment

Outcome | | Similarities | | | (nd on range)
| | N | B12 | | N | Placebo*
Baseline MEDIAN | (Range) | 16 | 7 (2–10) | | 16 | Same
Final MEDIAN | (Range) | 16 | 7 (2–10) | | 16 | 5 | (1–10)
Difference
P Difference | | NS | | | 0.04
Net Difference
P Net difference | | 0.05

* 1 month prior to B12 treatment

Text:

Performance onMMSE, Trail Making Test, Rivermead Behavioral Face Recognition Test, andDigit Span remained unchanged.

Intervention and Correlation

Author, Year: Bryan, 2002 | Ref ID: 10004 | Vitamins: B12, folate, B6
Objective: To investigate the effects of short-term supplementation in healthy women who took either 750 μg of folate, 15 μg of vitamin B12, 75 mg of vitamin B6 or a placebo daily for 35 days

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | RCT, double-blind | Age: | 74.08±5.75 SD 65–92 | Random sample of females from 3 age bands whose names were selected from the Australian Electoral Rolls, which contains 98% of the adult voting population. Healthy women who did not smoke, who were not pregnant or lactating, not taking oral contraceptives or HRT, and not taking any medication likely to affect mental performance or mood. English as a first language, or proficiency in English. | Missing pre- or post-treatment data | AD: | ND
Country: | Australia | %Male: | 0 | | | PD: | ND
Setting: | Population-based | Race: | ND | | | VascDz: | ND
Funding: | Australian Association of Gerontology | Education: | 11.48±3.29 yr | | | Other:
| | # of medical conditions: | 1.96±1.58
| | # of supplements: | 0.59±1.00
Comments: This study has 3 age groups of women: younger age, middle-aged, and older women. We focus on older women.

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
| | N enrolled: | Younger: 56 | ND | ND | ND
| | | Middle: 80
| | | Older: 75
| | | Total: 221
Folate 750 μg/day | | N analyzed: | Total: 211 | ND | ND | ND
Vitamin B12 15 μg/day | Placebo capsule | Drop-outs (%): | 4.5%
Vitamin B6 75 mg/day
Follow-up duration: 5 weeks | | Reasons for drop out: Incomplete data
Comments: Compliance was monitoring by pill counting. The percentage of each treatment group who reported taking more than 95% of the capsules was: folate, 96%; vitamin B12, 93%; vitamin B6, 94% and placebo, 88%

Primary outcome(s): | Cognitive measures:; 1 Speed of processing: Boxes Test, a measure of sensory-motor speed; and the Digit Symbol-Coding and Symbol Search subtests of the Wechsler Adult Intelligence Scale-III (WAIS-III), both measures of perceptual speed.; 2 Working memory: Digit Span-Backwards; Letter-Number Sequencing; 3 Memory: Rey Auditory-Verbal Learning Test (RAVLT); and 2 measures of incidental recall: recall of symbols from Digit-Symbol-Coding (WAIS-III) and Activity recall.; 4 Executive function: Executive function is conceptualized as a higher order cognitive function that controls and integrates other cognitive activities involved in planning and implementing strategies for performance, monitoring performance and using feedback to adjust future responding. Neuropsychological tests sensitive to frontal lobe function were used, including the Stroop Test; the Self-Ordered Pointing Task; Uses for Common Objects; The Trail Making Test; and Verbal Fluency, comprising Initial Letter Fluency and Excluded Letter Fluency.; 5 Verbal ability: Vocabulary (WAIS-III) and Spot-the-Word.
| Mood measures: Current mood state was assessed using 2 self-report questionnaires that were completed before the cognitive testing sessions: The Center for Epidemiological Studies-Depression Scale (CESD) and The Profile of Mood States Questionnaire (POMS)
Secondary outcome(s): | Effects of usual dietary intake on cognitive performance: Dietary intake at baseline was assessed using a self-completed, quantified, FFQ based on Baghurst and Record. This form of the FFQ is regularly updated and has been shown to have a high repeatability and consistency with other dietary intake measurement techniques and has demonstrated good reliability compared with urinary and protein measures. The nutrient composition of the food item per unit weight were taken from Australian and British food tables.
Adverse events: | ND
Limitations: | Lack of objective measures of B vitamin status, such as RBC levels, at baseline or dose-response relationships over time. Short duration.
Quality (A/B/C): B | Applicability (1/2/3): 1

Correlation of dietary usual intake of B vitamins and cognitive performance at baseline (or before supplementation)

Outcome(s): | Results (Text) (or Definition)
Cognitive measures:; 1 Speed of processing; 2 Working memory; 3 Memory; 4 Executive function; 5 Verbal ability | Folate intake affected Boxes performance across age groups (p<0.05), with those in the 2^nd^ intake quartile (65.05±12.91) completing significantly more boxes than those in the 3^rd^ (57.67±14.71) and 4^th^ (55.94±16.49). There were no effects of vitamin B12 intake on any other cognitive measure in older adults.
| There were no effects of vitamin B12 intake on any cognitive measure in older adults.
| There was an effect of vitamin B6 intake that interacted with age group for the short delay recall of the RAVLT (p<0.05), with older age group participants in the 2^nd^ (10.93±2.43) intake quartile recalling more words than those in the 1^st^ (7.40±3.47). There were no effects of vitamin B6 intake on any other cognitive measure in older adults.

*Older participants had relatively better folate, vitamin B12, and vitamin B6 status than younger and middle-aged women, based on the self-reported FFQ

| | Folate TUL 1000 μg RDI 200 μg | | | Vitamin B12 TUL 20 μg RDI 2 μg | | | Vitamin B6 TUL 100 mg RDI 0.8–1.1 mg
Age group, year | N | Range, μg | % < RDI | % < 0.7 RDI | Range, μg | % < RDI | % < 0.7 RDI | Range, μg | % < RDI | % < 0.7 RDI
Younger (20–30) | 56 | 98–668 | 29.1 | 12.7 | 0.37 | 20.0 | 9.1 | 0.7–4.3 | 3.6 | 0
Middle (45–55) | 80 | 64–942 | 21.3 | 8.8 | 1–14 | 12.5 | 5.0 | 1.4–5.7 | 2.5 | 0
Older (65–92) | 75 | 135–678 | 4.1 | 0 | 0.58–27 | 8.1 | 2.7 | 0.8–3.8 | 0 | 0
Total sample | 221 | 64–942 | 17.2 | 7.2 | 0.37–27 | 12.9 | 4.8 | 0.4–5.7 | 1.9 | 0

TUL = tolerable upper limit; % < RDI = percentage of participants below the Australian Recommended Daily Intake (RDI); % < 0.7 RDI = percentage of participants below 70% of the Australian RDI

Effects of short-term supplementation of B vitamins on cognitive performance at baseline

Outcome(s): | Results (Text) (or Definition)
Cognitive measures:; 1 Speed of processing; 2 Working memory; 3 Memory; 4 Executive function; 5 Verbal ability | There were significant main effects of age and/or time for many of the cognitive performance in which performance was more positive with increasing age and at time 2 than time 1, reflecting practice and placebo effects.
| Post hoc comparisons revealed that older age participants in the folate treatment group identified significantly more words than did those in the placebo group.
| Post hoc comparisons reveal the that participants in the vitamin B6 and placebo groups generated significantly more words than did those in the folate and vitamin B12 treatment group.

Intervention and Correlation

Author, Year: Clarke, 2003 | Ref ID: 41 | Vitamins: B12+folate
Objective: To assess the biochemical efficacy of vitamin supplements in people at high risk of dementia

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | RCT 2×2×2 factorial design | Age: | 75 (56 – 89) | | Patients who believed they had memory problems; TICS-M score<27; or clinical diagnosis of dementia (DSM IV criteria) and MMSE=12–26 or on therapy for cognitive function (e.g. Donepezil, Metrifonate, Rivastigmine) for at least 3 months | Fronto-temporal dementia; PD; Huntington's disease; normal pressure hydrocephalus; multivitamins (unless only folate<100mg daily); life-threatening disease or cancer; concern about likely compliance; nursing home residents; peptic ulcer or aspirin sensitivity | AD:
Country: | UK | %Male: | | | | | PD:
Setting: | outpatients | Race: | | | | | VascDz:
Funding: | Industry; government | Other: | | | | | Other: | Clinical Dx of dementia (DSM IV criteria) and MMSE=12–26 or mild cognitive impairment defined by symptoms and a modified TICS-M score<27
Comments: Age given only for total patients enrolled; AD: 84 patients; AD+VascDz: 11; VascDz: 3; cognitive impairment: 47; unknown: 4

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
B12: 1mg | placebo | N enrolled: | 149 | 74 | | 75
+folate: 2 mg | | N analyzed: | 128 | ND | | ND
| | Drop-outs (%): | 21 (14)
Follow-up duration: 12 weeks | | Reasons for drop out: ND
Comments: Interventions: aspirin vs. placebo; B12+folate vs. placebo; Vitamin E/C vs. placebo; N analyzed for cognitive function tests in each group not given

Primary outcome(s): | Biochemical endpoints (homocysteine; folate; B12; isoprostane; thromboxane)
Secondary outcome(s): | Cognitive function scores (MMSE; ADAS-Cog; Bristol Activities of Daily Living Scale)
Adverse events: | ND
Limitations: | Sample calculation not explicitly reported and not performed for treatment efficacy on cognitive function; results for treatment efficacy on cognitive function not mentioned as well as N analyzed in each group; reasons for drop-outs not given. ND on gender; race; small sample for each dementia type.
Quality (A/B/C): B | Applicability (1/2/3): 2

Outcome(s): | Results (Text) (or Definition)
MMSE, ADAS-Cog, ADL | Not significantly altered by treatment (specific results not shown)
Unadjusted Spearman correlation coefficient between baseline cognitive function scores and baseline level of folate*, B12* | Folate /MMSE: r=0.16, p<0.05; Folate /ADAS-Cog: r = - 0.22, p<0.01; Folate /ADL: r = - 0.20, p<0.05 B12 / MMSE: r= - 0.10, NS; B12/ ADAS-Cog: r= - 0.10, NS; B12/ ADL: r= 0.19, p<0.05
Age adjusted Spearman correlation coefficient between baseline cognitive function scores and baseline level of folate*, B12* | Folate /MMSE: r=0.15, NS; Folate /ADAS-Cog: r = - 0.20, p<0.05; Folate /ADL: r = - 0.19, p<0.05 B12 / MMSE: r= - 0. 05, NS; B12/ ADAS-Cog: r= 0.04, NS; B12/ ADL: r= 0.14, NS

* B12 levels determined by a competitive protein binding immunoassay (REF 23 in the paper); folate levels by a microbioogical method using cryopreserved, microtiter plate method (REF 24 in the paper). No data on normal range are given for any of the methods

Intervention and Correlation

Author, Year: Coimbra, 2003 | Ref ID: 641 | Vitamins: Riboflavin (Riboflavin, B6, Folate, B12)
Objective: Effect of riboflavin treatment on motor function in PD

Study characteristics | | Population | | Controls (Correlation) | Inclusion criteria | Exclusion criteria | Definitions
Study design | Prospective longitudinal cohort | Age: | 67.5 | 77.5 | Sporadic PD | | AD:
Country: | Brazil | %Male: | 42% | 50% | (Correlation controls: Dementia without stroke and a low Mini-Mental score) | (Stroke, ischemic brain lesions) | PD: | “Current criteria” (Fahn & Przedborski 2000)
Setting: | Neurology clinic outpatients | Race: | nd | nd | | | VascDz:
Funding: | nd | Other: Hoehn & Yahr Stages: 1, 2, 3 – 10% each; 4 – 26%; 5 – 45% | | | | | Other:
Comments:

Intervention

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Riboflavin 30 mg TID | None | N enrolled: | 31 | 31 | | 0
(eliminate all red meat from diets) | | N analyzed: | 19 | 19 | | 0
| | Drop-outs (%): | 39%
Follow-up duration: 6 mo | | Reasons for drop out: Failure to comply for 6 mo
Comments:

Primary outcome(s): | Motor capacity | Motor function scale based on expanded version of Hoehn & Yahr scale, with categories of 0 (Requires assistance to stand even on symptomatic drugs for PD), 14, 30, 50 (Unassisted basic care and reduced unsteadiness while on symptomatic drugs for PD), 65, 80 (Bilateral rigidity/tremor + midline changes with normal balance prior to the early morning symptomatic drugs for PD; continuous but reduced symptoms while on symptomatic drugs for PD), 90, 95, 100 (Fully asymptomatic without symptomatic drugs for PD)
Secondary outcome(s): | Reported symptoms
Adverse events: | nd
Limitations: | High dropout rate. Completers analysis only. No control. May be confounded by elimination of red meat from diet.
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text) (or Definition)
Reported symptoms | “About 10–15 days after beginning treatment, PD patients often reported better (progressively less interrupted) sleep at night, improved reasoning, higher motivation, and reduced depression. Their family members usually started noticing motor improvements after 20 days of treatment, but in some cases of advanced disability the patient was able to change body position in bed at night as early as on the third day of treatment.”

Outcome | Motor Capacity | (scale 0–100%) | | | 3 Months
| | N | Riboflavin | 30 mg TID | N | (Intervention) | (Dose) | N | (Intervention) | (Dose) | N | Control
Baseline value | (SE/SD) | 19 | 44 | nd
Final value | (SE/SD) | 19 | 66 | nd
Difference | (SE/SD/95% CI)
P Difference | | <0.001
Net Difference | (SE/SD/95% CI)
P Net difference

Outcome | Motor Capacity | (scale 0–100%) | | | 6 Months
| | N | Riboflavin | 30 mg TID | N | (Intervention) | (Dose) | N | (Intervention) | (Dose) | N | Control
Baseline value | (SE/SD) | 19 | 44 | nd
Final value | (SE/SD) | 19 | 71 | nd
Difference | (SE/SD/95% CI)
P Difference | | <0.001
Net Difference | (SE/SD/95% CI)
P Net difference

Correlation (Baseline)

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Plasma Riboflavin* | ng/mL | PD v Dementia without stroke | | N enrolled: | 41 | 31 | 10
Plasma Vitamin B6** | ng/mL | | | N analyzed: | 41 | 31 | 10
Plasma Folate*** | ng/mL
SerumVitamin B12**** | pg/mL | | | Drop-outs (%):
Comments:

* Flavin-adenin dinucleotide, HPLC/fluorometric detection, per Speek AJ 1982. ND on normal range.

** Per Sharma SK 1992. ND on normal range.

*** HPLC/microbiological assay, per Kelly P 1996. ND on normal range.

**** Roche Diganostics, electrochemiluminescence immunoassay. ND on normal range.

Other predictors/outcomes reported: | Hcy
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): | Applicability (1/2/3):

Correlation of Predictors with Outcomes (Baseline)

Description of (Sub-) Groups | Outcome | N | Plasma | Riboflavin | ng/mL | Plasma | B6 | nmol/L | Plasma | Folate | ng/mL | Serum | B12 | pg/mL
| | | Mean | SD | | Mean | SD | | Mean | SD | | Mean | SD
PD | | 31 | 100.9 | 22.0 | | 25.3 | 6.1 | | 5.6 | 4.0 | | 356.0 | 261.0
Dementia w/o Stroke | | 10 | 128.8 | 25.6 | | 24.3 | 9.4 | | 4.3 | 2.8 | | 440.7 | 322.5
| P difference | | <0.01 | | | NS | | | NS | | | NS

Intervention and Correlation

Author, Year: Kral, 1970 | Ref ID: 1694 | Vitamins: B12, folate
Objective: To determine the correlation of vit B12 and folic acid levels with the degree of memory impairment and whether parenteral administration of vit B12 would improve their memory function

Study characteristics | | Population | | | Controls for RCT | Inclusion criteria | Exclusion criteria | Definitions
| | | XS-1 | RCT-2
Study design | XS-part 1 | Age: | 77 | nd | nd | Geriatric ward and homes for the aged in the Montreal area | Subacute combined degeneration, sensory deficiencies; aphasia; those on vitamins, anticonvulsants, chemotherapy, blood transfusions | AD: | nd
| CT-part2
Country: | Canada | %Male: | 59% | 39% | 55% | | | PD: | nd
Setting: | University and community | Race: | nd | nd | nd | | | VascDz: | nd
Funding: | Gov | Other: | | | | | | Other: | nd
Comments: | Part 1 correlation: 12 without psychological or neurological symptoms; 9 senile dementia; 24 cerebral arteriosclerosis; 18 diagnosis undetermined
| Part 2 was Intervention: 18 formed the experimental group; 22 the control group

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Vit B12 × 5times/wk × 14 wk | No treatment | N enrolled: | Part 1: 63
| | | Part 2: 40 | 18 | | 22
| | N analyzed: | Part 1: 53
| | | Part 2: 40 | 18 | | 22
| | Drop-outs (%): | nd
Follow-up duration: 14 wk | | Reasons for drop out: nd
Comments: Vit B12 <200 μmg/ml; folic acid <4 μmg/ml were considered as vitamin deficient

Sr vit B12 measured by microbiological assay according to the method of Ross using Euglena gracilis

Sr folic acid was determined by the method of Baker using Lactobacillus casei in a microbiological assay

Primary outcome(s): | Part 1: correlation of vitamins with memory impairment | Part 2: Comparison of change in memory quotient between treatment and control groups
Secondary outcome(s): | weight
Adverse events: | ND
Limitations: | Results presents as text only; 53 analyzed not randomized; but single blinded study
Quality (A/B/C): C | Applicability (1/2/3): 1

Memory function was measured by the standardWechsler Memory Scale. The upper and lower limit of retention span was done using counting test (Cameron 1943)

Outcome(s): | Results (Text) (or Definition)
Memory quotient | The correlation study did not reveal any significant correlation between the level of serum vit B12 or folic acid and any measure of senile impairment in the population as a whole.
| The same analysis performed separately for each sex it was found that in women the serum vit B12 level was positively correlated within MQ at the 0.1 level of significance
Treatment effect | No significant change of the MQ was observed in either the vit B12 deficient subgroup, or in the subgroup with folate def as a result of treatment
| In the subgroup with combined def, the MQ of the 2 experimental subjects increased minimally, whereas the mean MQ of the two experimental subjects dropped sig after the treatment

Number of subjects | MQ >100 | 80–100 | 60–80 | <60
Average Sr B12 μμmg/ml | 294 | 409 | 304 | 153
Average Sr folate μmg/ml | 5.20 | 4.00 | 6.96 | 8.30
Ratio Folate/B12 | 1:56 | 1:100 | 1:42 | 1:18
B12 to folate ratio did not correlate with MQ, but correlated positive at the 0.01 level of significance with the senile score on the age relevant check list

Memory Quotient | (0–100)
| | N | Vit B12 5x/wk | 7000 mg (total) | N | Control
Baseline value | (ND) | 18 | 90 | | 22 | 88
Final value | (ND) | 18 | 87 | | 22 | 92
Difference | (ND) | | -3 | | +4
P Difference | | NS
Net Difference
P Net difference | | NS

Lower limit of retention span | ND
| | N | Vit B12 5x/wk | 7000 mg (total) | N | Control
Baseline value | (ND) | 18 | 38 | | 22 | 45
Final value | (ND) | 18 | 26 | | 22 | 27
Difference | (ND) | | -12 | | +4
P Difference | | NS | | | NS
Net Difference
P Net difference | | NS

Upper limit of retention span | ND
| | N | Vit B12 5x/wk | 7000 mg (total) | N | Control
Baseline value | (ND) | 18 | 48 | | 22 | 45
Final value | (ND) | 18 | 42 | | 22 | 72
Difference | (ND) | | -6 | | -5
P Difference | | NS | | | NS
Net Difference
P Net difference | | NS

Correlation and Intervention

Author, Year: Lewerin, 2005 | Ref ID: 10002 | Vitamins: B12/Folate/B6
Objective: Multi-B vitamin for cognitive and movement in general population elderly

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | RCT | Age: | 75.7 +\-4.7 | 75.6 +\-4.0 | Community dwelling men and women who underwent cognitive testing and Postural-Locomotor-Manual testing | | AD:
Country: | Sweden | %Male: | 38% | 44% | | | PD:
Setting: | Community | Race: | nd | nd | | | VascDz:
Funding: | Private | Other: | | | | | Other:
Comments:

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Cyanocobalamin 500 μg/day | Placebo | N enrolled: | 195 | 126 | | 69
Folate 800 μg/day | | N analyzed: | | 105–115 | | 57–64
Vit B6 HCl 3 mg/day | | Drop-outs (%):
Follow-up duration: 4 mo | | Reasons for drop out: Illness, difficulty/pain, refusal, poor compliance (7), other
Comments: Tests performed at different visits. Different numbers evaluated for different tests.

RCT

Primary outcome(s): | Cognitive and Postural-Locomotor-Manual tests
Secondary outcome(s):
Adverse events: | nd
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 3

Outcome(s): | Definition
Postural-Locomotor-Manual testing (movement time) | Opto-electronic technique to evaluate time to lift, carry, and deposit an object
Simultaneity index | Overlap time of different phases (sum of times of 3 individual phases/total time)
Digit span forward and backward | Short term memory
Identical forms | Perceptual speed (time to marking identical form)
Visual reproduction | Visual memory (ability to remember and draw 4 forms)
Synonyms | Verbal ability (finding synonyms)
Block design | Spatial ability (reproduce design with colored blocks)
Digit symbol | Perceptual speed (time to replace digits with symbols by a code)
Thurstone's Picture Memory Test | Long term memory (ability to remember pictures)
Figure classification | Inductive reasoning (ability to choose figure different from others)

Baseline Correlation

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Plasma Folate* | nmol/L | Movement time | | N enrolled: | 209 | All evaluated together | N/A
Whole blood Folate** | nmol/L | Simultaneity index | | N analyzed: | 195–207
Serum Vit B12*** | pmol/L | Block design | | Drop-outs (%):
(Serum MMA | μmol/L) | Digit symbol
(Plasma Homocysteine | μmol/L)
Comments: 14 subjects were excluded from RCT prior to start of RCT because of “difficulty/pain”.

MMA, methylmalonic acid

* Diagnostic Products Corp, Solid Phase No Boil Dualcount. Normal range: 6–35 nmol/L.

** Diagnostic Products Corp, Solid Phase No Boil Dualcount. Normal range: 100–450 nmol/L.

*** Diagnostic Products Corp, Solid Phase No Boil Dualcount. Normal range: 130–750 pmol /L.

Correlation of Predictors with Outcomes (Baseline): Multivariate analysis*

Description of (Sub-) Groups | N | Plasma | Folate | nmol/L | | | Whole blood | Folate | nmol/L | | | Serum | B12 | pmol/L
| | Mean | SD | β | R^2^ | P | Mean | SD | β | R^2^ | P | Mean | SD | β | R^2^ | P
All: Block Design (WAIS) | 207 | 16.0 | 6.61 | +0.029 | 0.13 | NS | 351 | 134.9 | -0031 | 0.13 | NS | 325 | 159.3 | +0.0028 | 0.13 | NS
All: Digit Symbol (WAIS) | 204 | | | +0.083 | 0.10 | NS | | | -0.004 | 0.10 | NS | | | +0.0038 | 0.10 | NS

β, Regression coefficient

* Adjusted for age, sex, smoking, serum creatinine

Digit Span Forward (WAIS) | (0–9)
| | N | B vitamins | | N | Control
Baseline value | (SD) | 115 | 5.8 | 1.1 | 64 | 5.9 | 1.2
Final value | | 115 | | | 64
Difference | (SEM) | +0.24 | | 0.09 | +0.33 | | 0.14
P Difference
Net Difference
P Net difference | | NS

Digit Span Backward (WAIS) | (0–8)
| | N | B vitamins | | N | Control
Baseline value | (SD) | 115 | 4.4 | 1.2 | 64 | 4.6 | 1.0
Final value | | 115 | | | 64
Difference | (SEM) | +0.25 | | 0.09 | +0.22 | | 0.16
P Difference
Net Difference
P Net difference | | NS

Identical Forms | (0–60)
| | N | B vitamins | | N | Control
Baseline value | (SD) | 115 | 23.3 | 7.6 | 61 | 24.8 | 8.1
Final value | | 115 | | | 61
Difference | (SEM) | +0.13 | | 0.37 | +1.5 | | 0.56
P Difference
Net Difference
P Net difference | | 0.04*

* Note placebo better than B vitamins

Visual Reproduction | (0–14)
| | N | B vitamins | | N | Control
Baseline value | (SD) | 113 | 6.9 | 3.1 | 62 | 7.0 | 3.0
Final value | | 113 | | | 62
Difference | (SEM) | +0.61 | | 0.23 | +0.6 | | 0.28
P Difference
Net Difference
P Net difference | | NS

Synonyms | (0–30)
| | N | B vitamins | | N | Control
Baseline value | (SD) | 110 | 22.5 | 4.7 | 61 | 22.4 | 5.0
Final value | | 110 | | | 61
Difference | (SEM) | +0.31 | | 0.25 | +1.3 | | 0.3
P Difference
Net Difference
P Net difference | | 0.02*

* Note placebo better than B vitamins

Block Design (WAIS) | (0–42)
| | N | B vitamins | | N | Control
Baseline value | (SD) | 114 | 18.5 | 6.3 | 61 | 20.0 | 7.7
Final value | | 114 | | | 61
Difference | (SEM) | +0.99 | | 0.37 | +0.80 | | 0.50
P Difference
Net Difference
P Net difference | | NS

Digit Symbol (WAIS) | (0–90)
| | N | B vitamins | | N | Control
Baseline value | (SD) | 113 | 35.1 | 10.0 | 62 | 38.0 | 12.1
Final value | | 113 | | | 62
Difference | (SEM) | +0.95 | | 0.52 | +2.31 | | 0.51
P Difference
Net Difference
P Net difference | | 0.09*

* Note placebo better than B vitamins

Thurstone's Picture Memory Test | (0–28)
| | N | B vitamins | | N | Control
Baseline value | (SD) | 115 | 20.3 | 4.8 | 63 | 21.1 | 3.9
Final value | | 115 | | | 63
Difference | (SEM) | +1.75 | | 0.30 | +2.41 | | 0.42
P Difference
Net Difference
P Net difference | | NS

Figure Classification | (0–30)
| | N | B vitamins | | N | Control
Baseline value | (SD) | 113 | 15.8 | 4.8 | 62 | 16.8 | 4.9
Final value | | 113 | | | 62
Difference | (SEM) | +1.45 | | 0.33 | +0.60 | | 0.55
P Difference
Net Difference
P Net difference | | NS

Neither basal Hcy, MMA, B12, folate showed associations with change in cognitive performance.

Intervention and Correlation

Author, Year: Mitsuyama, 1988 | Ref ID: 2185 | Vitamins: B12
Objective: To examine the effect of CH3-B12 on the CNS and clinical effectiveness for organic mental symptoms. To determine the correlation between the serum vitB12 and CSF vitB12

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Non comparative open trial and correlational study | Age: | 53±3.1 (34–77) | | Subjects who fulfilled the clinical criteria of dementia. Confirmed in all patients by the finding of cerebral atrophy and widening of the ventricles on the CT scan. | Any disorder known to affect vit B12 metabolism, such as acute physical disease, malnutrition, severe anemia, and myeloproliferative disorders and abnormal kidney and liver disorders | AD: | Same as inclusion criteria
Country: | Japan | %Male: | 64% | | | | PD: | NA
Setting: | Academic hospital | Race: | 100% Asian | | | | VascDz: | NA
Funding: | ND | Other: | | | | | Other: | Pick's disease
Comments: 4 patients were mildly demented; 7 moderately demented; 3 patients were severely demented

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Vit B12 2mg/d for 60d | None | N enrolled: | 14 | 5 | 9
Vit B12 2 mg/d PO and 500μg/d IM | | N analyzed: | 14 | 5 | 9
| | Drop-outs (%): | 0
Follow-up duration: 60 days | | Reasons for drop out: NA
Comments: Sr and CSF B12 assessed by radioassay range between 25 to 1600 pg/mL

Primary outcome(s): | Change in GBS scale (a neuropsychological scale developed by Gottfries) | | Correlation between serum and CSF vit B12
Secondary outcome(s): | Correlation of sr and CSF-VB 12 with severity of dementia
Adverse events: | ND
Limitations: | Small sample size ( only 1 patient with AD and W-K); 1 patient had unclassified presenile dementia; all mostly had pick's disease
Quality (A/B/C): | B (comparative trial and small sample size) | Applicability (1/2/3): 2 | Broad range of dementia

Outcome(s): | Results (Text) (or Definition)
Correlation of Serum and CSF Vit B12 with severity of dementia | No correlation between the concentration of serum and CSF vit B12 levels and severity of dementia without B12 administration
Change in GBS scale | No change in GBS scale with administration of CH3-B12. However patients on both PO and IM reported improvement in mood and social behavioral changes and enhanced self rating of competencies

Intervention and Correlation

Author, Year: Shaw | Ref ID: 2954 | Vitamins: Folate, B12
Objective: Effect of B12/Folate on cognitive function in patients with AD and low folate

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Randomized Xover | Age: | 80.6+/-6.7 | | In-patients diagnosed with senile dementia. RBC folate <130 ng/mL | Serious impairment of cardiac, pulmonary or renal function. Cerebral arteriosclerosis | AD:
Country: | UK | %Male: | nd | | | | PD:
Setting: | In-patients | Race: | nd | | | | VascDz:
Funding: | nd | Other: | | | | | Other:
Comments: Double blind. No washout.

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
Hydroxycobalamin 1000 μg IM × 7 days, then weekly | Placebos | N enrolled: | 66 | 66 | | 66
| | N analyzed: | 17 | 17 (10 first arm) | | 17 (7 first arm)
Folate 15 mg po daily | | Drop-outs (%): | 74%
Follow-up duration: 12 wk | | Reasons for drop out: “Patients selected were severely demented and many had difficulty in cooperating sufficiently” on testing
Comments:

Primary outcome(s): | Psychometry (see tests below)
Secondary outcome(s): | Folate, B12, other levels
Adverse events: | nd
Limitations: | Inappropriate tests used for such severely demented group. Thus ¾ dropouts. Data incomplete.
Quality (A/B/C): C | Applicability (1/2/3): 1

Outcome(s): | Definition
Synonym Learning Test
Digit Copying Score | Kendrick 1967
Dementia Scale (without Changes in Personality)
Information-Memory-Concentration Test | Blessed 1968

[underlined: Intervention]

The means for the Dementia Scales were unchanged in both groups. Those for The Information-Memory-Concentration scores rose slightly, but the increment was not statistically significant.

Correlation

Author, Year: Andersen-Ranberg, 2001 | Ref ID: 119 | Vitamins: B12, Folate
Objective: Relation of dementia to other diseases

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 100 | Cases: | Cases: | AD:
| Comparative | %Male: | 22% | All individuals in Denmark turning 100 y.o. between 4/1/95 and 5/31/96. | Refused (n=56). Died within weeks of birthday, prior to contact (n=13). Missing data (n=11).
| Prospective | Race: | nd | | | PD:
Country: | Denmark | Other: | | Controls: | Controls: | VascDz:
Setting: | Population | | | | | Dementia: | WHO (1992) ICD-10. Severity rated by Clinical Dementia Rating (CDR; Hughes et al, 1982)
Funding: | Government
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
“B12 or Folate deficiency” | nd | Demented | ICD-10 | N eligible: | 276
| | | | N analyzed: | 196 | 105 | 91
| | | | Drop-outs (%):
Comments:

Other predictors/outcomes reported: | CVD, DM, Hypothyroid, PD
Follow-up duration (if applicable):
Reasons for drop out (if applicable): | See Exclusion criteria
Limitations: | Limited details or analyses. Centenarians only.
Quality (A/B/C): C | Applicability (1/2/3): 1

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Serum | B12 or Folate deficiency | (nd) | p
| | n | %
Demented | 105 | 9 | 9% | | nd
Non-demented | 91 | 10 | 11%

Correlation

Author, Year: Anello, 2004 | Ref ID: 123 | Vitamins: Folate, B12
Objective: MTHFR polymorphisms and AD

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 71.0+/-6.6 | 69.5+/-12.7 | Cases: | Cases: | AD: | CERAD
| Comparative | %Male: | nd | nd | Ambulatory, AD
| Prospective | Race: | nd | nd | | | PD:
Country: | Italy | Raiseberg score >6: | 30% | | Controls: | Controls: | VascDz:
Setting: | Clinic | Early onset (<65 y) AD: | 23% | | Ambulatory, from same geographical area | AD | Other:
Funding: | nd
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Vitamin B12* | pmol/L | AD Diagnosis | | N enrolled: | 361 | 180 | 181
Folates* | nmol/L | Dementia severity | Reisberg scale (1982) | N analyzed: | 361 | 180 | 181
Homocysteine | μmol/L | Age of AD onset | Early: <65 y
ApoE ε4
MTHFR | | | | Drop-outs (%):
Comments:

* Abbott IMX automated Benchtop analyzer system, Microparticle enzyme immunoassay (MEIA). No data on normal range.

Other predictors/outcomes reported: | Transcobalamin gene (TCN1)
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 2

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Plasma | B12 | pmol/L | p | Plasma | Folates | nmol/L | p | (Sr/CSF) | (B vit) | (unit) | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | SD | | | Mean | SD | | | Mean | SE/SD | r= | Mean | SE/SD | r=
AD | 180 | 278 | 221 | | NS | 14.3 | 5.7 | | 0.09
Controls | 181 | 283 | 211 | | | 15.7 | 5.9

Logistic Regression Predictors: | N | Diagnosis of AD
| | OR (Unadjusted) | | P (univariate) | P (multivariate*)
Folate | 361 | 0.95 | (0.91,1.00) | 0.04 | NS (0.2)
Vitamin B12 | | 1 | (0.99,1.01) | NS | NS

* Adjusted for MTHFR, ApoE ε4, and TCN1 genotypes, and homocysteine level (and other B vitamin)

Outcome(s): | Results (Text)
Severity of dementia (Reisberg scale) | “Plasma levels of (Hcy,) folate and vitamin B12 were not influenced by the severity of dementia or age of onset of the disease.”

Correlation

Author, Year: Argyriadou, 2001 | Ref ID: 144 | Vitamins: B12, Folate
Objective: Association between cognitive impairment and anemia

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 65–74: 50% | Cases: | Cases: | AD:
| | | 75–84: 35% | Age ≥65 y
| | | 85+: 15% | a living in geriatric facility (n=48),; b visit geriatric community center (n=75),; c received routine care at health center (n=413)
| Non-comparative | %Male: | 46%
| Prospective | Race: | nd | | | PD:
Country: | Greece | Other: | | Controls: | Controls: | VascDz:
Setting: | Community | | | | | Possible cognitive impairment: | MMSE≤24
Funding: | nd (report no conflicting interests)
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Vitamin B12 (normal v abnormal)* | Abnl: <145 pg/mL | MMSE | | N enrolled: | | 536
Folate (normal v abnormal)* | Abnl: <1.8 ng/mL | | | N analyzed: | | 536
| | | | Drop-outs (%):
Comments:

* Micro Merieux analyzer, ELISA.

** Imx automatic analyzer, Ion Capture Immune Assay (ICIA).

Other predictors/outcomes reported: | Hematocrit, Age
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Limited analyses. Potentially biased sample due to eligibility criteria
Quality (A/B/C): C | Applicability (1/2/3): 3

Outcome(s): | Results (Text)

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | | p | N | | p | N | | p
| (Total) | % | | (Men) | % | | (Women) | %
Normal B12 (≥145 pg/mL)
MMSE ≤24 | 480 | 37.9% | | 221 | 34.8% | | 259 | 40.50%
MMSE >24 | | 62.1% | | | 65.2% | | | 59.5%
Low B12 (<145 pg/mL)
MMSE ≤24 | 56 | 55.4% | nd | 24 | 62.5% | 0.008 | 32 | 50% | NS
MMSE >24 | | 44.6% | | | 37.5% | | | 50%
Normal Folate (≥1.8 ng/mL)
MMSE ≤24 | 521 | 39.5% | | 239 | 37.7% | | 282 | 41.1%
MMSE >24 | | 60.3% | | | 62.3% | | | 58.9%
Low Folate (<1.8 ng/mL)
MMSE ≤24 | 15 | 46.7% | NS | 6 | 33.3% | | 9 | 55.6%
MMSE >24 | | 53.3% | | 66.7% | 66.7% | | | 44.4%

Logistic Regression Predictors: | N | MMSE ≤24
| | OR (Adjusted*) | | P (multivariate)
Low B12 (<145 pg/mL) | 536 | 2.0 | (1.1, 4.0) | 0.03
Low Folate (<1.8 ng/mL) | | 3.8 | (0.9, 15.2) | 0.06

* Adjusted for age, intake site, and presence of anemia (and other B vitamin)

Correlation

Author, Year: Assantachai, 1997 | Ref ID: 157 | Vitamins: B1, B12, Folate
Objective: Association of B1, B12, and folate deficiency and cognitive impairment

Study characteristics | | Population | | | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 69.3 | (60–87) | Cases: | Cases: | AD:
| Non-comparative | %Male: | 39% | | Enrolled in geriatric day centers, independently living, “well living”.
| Prospective | Race: | Thai | | | | PD:
Country: | Thailand | TMSE: | 27.38 | (2.02) | Controls: | Controls: | VascDz:
Setting: | Community (rural) | | | | | | Cognitive impairment: | TMSE<24
Funding: | nd
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Thiamin pyrophosphate effect (normal: 0–15%)* | % | Thai Mental State Examination (TMSE)* | 6 categories (orientation, registration, attention, calculation, language, abstract thinking, recall) | N enrolled: | | 203
Vitamin B12** | pg/mL | | Maximum 30 | N analyzed:
RBC Folate*** | ng/mL | | | Drop-outs (%):
Comments:

* Spectrophotometry. No data on normal range.

57 Radiodiolution assay (Co). No data on normal range.

*** Microbioassay using lactobacillus casei ATCC 7469 and spectrophotometry. No data on normal range.

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 3

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | Serum B1 effect (%) | | | | Serum B12 (pg/mL) | | | | RBC Folate (ng/mL)
| N | Mean | SD | P | N | Mean | SD | P | N | Mean | SD | P
Cognitively impaired (TMSE<24) | 63 | 12.44 | 8.81 | NS | 51 | 460 | 488 | NS | 44 | 416 | 123 | NS
Normal (TMSE≥24) | 138 | 10.90 | 7.68 | | 108 | 408 | 184 | | 103 | 399 | 143

Correlation

Author, Year: Bernard, 1998 | Ref ID: 269 | Vitamins: B12
Objective: Association of B12 (different measurements) and cognitive impairment

Study characteristics | | Population | | | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 71.5 | (65–89) | Cases: | Cases: | AD:
| Non-comparative | %Male: | 99% | | Ambulatory veterans, age≥65 y, who came to outpatient laboratory
| Prospective | Race: | White* | 88% | | | PD:
| | | Black | 9%
| | | Other | 3%
Country: | US | Other: | | | Controls: | Controls: | VascDz:
Setting: | Community (VA) | | | | | | Other:
Funding: | Government
Comments:

* Non-Hispanic

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
B12 deficiency | < laboratory norm (200 pg/mL)* | MMSE | | N enrolled: | | 303
B12 deficiency | < laboratory norm (200 pg/mL)* or >200 & <300 pg/mL & either MMA >2 SD above normal (271) or Hcy >2 SD above normal (16) | | | N analyzed: | | 303
| | | | Drop-outs (%):
Comments:

* No data on measurement method.

Other predictors/outcomes reported: | RAND 36-Item Health Survey
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 2

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | MMSE | (0–30) | p | BDS
| | Mean* | SD | | Mean
B12 <200 pg/mL | 19 | 22.54 | 1.89 | <0.05 | 4.19
B12 ≥200 pg/mL | 284 | 27.21 | 2.02 | | 4.07
| | | | | 4.17
B12 deficient (broad)** | 49 | 26.78 | 2.04 | NS (0.15) | 4.00
B12 normal (broad) | 254 | 27.25 | 2.01

* Least Squares mean (adjusted for alcohol intake (yes/no), vitamin use, annual income (dichotomous at $10,000), level of education.

** < laboratory norm (200 pg/mL) or (>200 & <300 pg/mL & either MMA >271 or Hcy >16)

Correlation

Author, Year: Bowirrat, 2002 | Ref ID: 395 | Vitamins: B12, Folate
Objective: Evaluation of dissociation between AD and ApoE ε4 in population of Arabs

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | Longitudinal | Age: | | Cases: Age ≥60 y, resident in 3 Arab villages in northern Israel | Cases: Refused to participate (n=12) | AD: | DSM- IV
| Non-comparative | %Male:
| Prospective | Race: | Arab | | | PD:
Country: | Israel | Other: | | Controls: | Controls: | VascDz:
Setting: | Community (rural) | | | | | Other:
Funding: Government, Private non-profit, Industry
Comments:

Predictor(s): (eg, B vit level) | Outcome(s): Dementia of the Alzheimer type (DAT) | Definition: DSM IV | | Total | Population of interest | Control
Plasma B12* | | | N surveyed: | 823
Plasma Folate* | Incident (new onset) DAT | | N analyzed: | 234 | 76 | 158
Comments:

* No data on methodology used or normal range.

Other predictors/outcomes reported: | ApoE ε4, age, concomitant medical conditions, smoking
Follow-up duration (if applicable): | Mean 20+/-4 (up to 23.4) months
Reasons for drop out (if applicable): | Labwork drawn only from 234/823 subjects
Limitations: | No results data reported, "perhaps the lowest ApoE ε4 frequency reported in the world: 3.5% Cx, 4.5% AD)
Quality (A/B/C): C | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
Baseline AD prevalence | Plasma B12 and plasma folate levels did not differ significantly between AD patients and controls after adjusting for year of birth.
AD incidence | Subjects (in the highest Hcy tertile or) in the lowest B12 and folate tertile did not have greater risk to develop AD after adjustment for year of birth and gender.

Correlation

Author, Year: Bunce, 2004 | Ref ID: 444 | Vitamins: B12, Folate
Objective: Association of ApoE ε5;4 and B12/Folate with cognitive impairment

Study characteristics | | Population | | | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 82.8 | (5.7) | Cases: Age ≥75 y, | Cases: Dementia, depression, incomplete laboratory data, B12 or folate supplementation, “abnormally high” folate levels | AD: | DSM-III-R
| Non-comparative | %Male: | 20%
| Prospective | Race: | nd | | | | PD:
Country: | Sweden | Other: | | | Controls: | Controls: | VascDz:
Setting: | Community | | | | | | Other:
Funding: Government, Private non-profit
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | | | Total | Population of interest | Control
Serum B12* | pmol/L | Free recall of sematically unrelated words | 2 lists of 12 concrete nouns, presented slowly or rapidly, immediate recall | N potential from survey: | | 528
SerumFolate* | nmol/L | Free and cued recall of organizable words | 23 nouns belonging to categories, presented slowly | N analyzed: | | 167
ApoE genotype
Comments:

* Radioimmunoassay. No data on normal range.

Other predictors/outcomes reported
Follow-up duration (if applicable):
Reasons for drop out (if applicable): | See Exclusions
Limitations: | Multiple exclusions and missing data
Quality (A/B/C): B | Applicability (1/2/3): 2

* Multiple detailed ANOVA and ANCOVA results were reported.

Correlation

Author, Year: Bunce, 2005 | Ref ID: 445 | Vitamins: B12, Folate
Objective: Association of B vitamin with cognition, correlation with ApoE genotype

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 82.8 | Cases: ≥75 y | Cases: Dementia, clinical depression, incomplete B12 or folate data, B12 or folate supplement, abnormally high folate, ApoE data unavailable | Dementia:: | DSM III-R
| Non-comparative | %Male: | 20%
| Prospective | Race: | ~100% white | | | PD:
Country: | Sweden | Other: | 8.9 yr education | | | VascDz:
Setting: | Community | | | | | Other:
Funding: Private and Government
Comments: Excluded people with dementia

Predictor(s): (eg, B vit level) | | Outcome(s): | | | Total | Population of interest | Control
Serum B12* | Low: <251 pmol/L | Face recognition: | 20 famous faces from 1930-1950 & 20 contemporary 1980s | N enrolled: | 167 | Non-demented | none
Serum Folate* | Low: <13 nmol/L | Short term memory | WAIS-R forward and backward digit span (FDS, BDS) | N analyzed: | 167
ApoE genotype | ε4 vs non-ε4 | Visuospatial ability | WAIS-R Block design test, Clock setting and reading ability | Drop-outs (%): | (361 did not meet criteria, including 150 with incomplete data and 32 with elevated folate level)
Comments:

* Radioimmunoassay

Other predictors/outcomes reported | none
Follow-up duration (if applicable): | NA
Reasons for drop out (if applicable): | NA
Limitations: | Excluded people with dementia, Did not analyze B vitamins as continuous variables.
Quality (A/B/C): B | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
Recognition of contemporary and dated famous faces | Low B12 (<251 pmol/L) significantly associated with poorer face recognition scores (p=0.008).
B12 and ApoE | Two-way interaction of B12 and ApoE (ε4 vs non-ε4) non-significant
Visuospatial skills | No significant associations for Clock reading, or Clock drawing
B12 and ApoE
Recognition of contemporary and dated famous faces | Low Folate (<13 nmol/L) significantly associated with poorer face recognition scores (p=0.011).
Folate and ApoE | Two-way interaction of Folate and ApoE (ε4 vs non-ε4) non-significant
Visuospatial skills | No significant associations for Clock reading, or Clock drawing
Folate and ApoE

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | FDS | (0–9) | p | BDS | (0–9) | p | Block Design | (0–42) | p
| | Mean | SD | | Mean | SD | | Mean | SD
ApoE ε4 Normal B12 | 21 | 5.52 | 1.29 | NS* | 4.19 | 1.03 | NS* | 13.95 | 4.53 | NS*
ApoE ε4 Low B12 (<251 pmol/L) | 28 | 5.36 | 0.91 | | 4.07 | 0.94 | | 12.32 | 4.30
ApoE non-ε4 Normal B12 | 64 | 5.83 | 1.15 | | 4.17 | 1.11 | | 14.95 | 5.55
ApoE non-ε4 Low B12 (<251 pmol/L) | 54 | 5.26 | 1.09 | | 4.00 | 1.06 | | 11.33 | 5.72
ApoE ε4 Normal Folate | 34 | 5.47 | 1.21 | NS* | 4.00 | 0.92 | NS* | 13.56 | 3.83 | NS*
ApoE ε4 Low Folate (<13 nmol/L) | 15 | 5.33 | 0.72 | | 4.40 | 1.06 | | 11.80 | 5.51
ApoE non-ε4 Normal Folate | 88 | 5.57 | 1.10 | | 4.15 | 1.07 | | 13.56 | 5.88
ApoE non-ε4 Low Folate (<13 nmol/L) | 30 | 5.57 | 1.10 | | 3.93 | 1.14 | | 12.79 | 5.93

FDS, WAIS-R forward digit span; BDS, WAIS-R backward digit span;

* NS by ANCOVA adjusted for age, years of education, gender, stroke, coronary heart disease, other heart disease and diabetes, and cerebrovascular disease.

Correlation

Author, Year: Cacabelos, 2004 | Ref ID: 477 | Vitamins: B12, Folate
Objective: Comparison of AD and vascular dementia

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 71 | 70 | Cases: Diagnosed with AD by conventional criteria. MMSE<24 and Hachinski<6 | Cases: | AD: | DSM-IV, NINCDS-ADRDA, ICD-10
| Comparative | %Male: | 36% | 45%
| Prospective | Race: | nd | nd | | | PD:
Country: | Spain | Other: | | | Controls: Diagnosed with dementia with vascular component, including vascular dementia, mixed dementia, and patients with cerebrovascular disorders, MMSE<24, Hachinski>6 | Controls: | Vascular dementia | NINDS-AIREN
Setting: | nd | | | | | | Cerebrovascular disorders: | Stroke, cardiogenic and/or hypertensive vascular encephalopathy, chronic cerebrovascular insufficiency
Funding: | nd
Comments: Source of subjects unclear

Predictor(s): (eg, B vit level) | | Outcome(s): Dx AD | Definition: | | Total | Population of interest | Control
Folate (blood)* | ng/mL | | | N enrolled:
Vitamin B12 (blood)** | pg/mL | | | N analyzed: | 939 | 465 | 474
Interaction with ApoE genotype | 2/3 v 2/4 v 3/3 v 3/4 v 4/4 | | | Drop-outs (%):
Comments:

* No data on measurement technique. Folate deficiency defined as folate < 3.0 ng/mL.

** No data on measurement technique. B12 deficiency defined as B12 < 150 pg/mL.

Other predictors/outcomes reported: | 107 laboratory, radiographic, history, physical examination variables, genomics
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | No correction for multiple testing or adjustments made
Quality (A/B/C): B | Applicability (1/2/3): (no data on source of sample) 2

Outcome(s): | Results (Text)
Folate interaction with ApoE genotype | No significant difference in folate levels between patients with AD and specific ApoE genotypes and their counterparts with vascular dementia.
B12 interaction with ApoE genotype | Patients with AD and ApoE 2/4 (n=4 or 6) had significantly lower B12 level (364+/-141 pg/mL) than patients with vascular dementia and ApoE 2/4 (n=9; 678+/-365 pg/mL;P<0.04). AD patients with other genotypes had similar B12 levels as their counterparts with vascular dementia.

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Blood | Folate | ng/mL | p | Blood | B12 | pg/mL | p
| | Mean | SD | Deficiency* | | Mean | SD | Deficiency**
AD | 465 | 6.10 | 2.81 | 5% | NS (mean) | 487.95 | 327.83 | 4% | NS (mean)
Vascular dementia | 474 | 6.31 | 3.13 | 6% | | 520.98 | 504.80 | 3%

* < 3.0 ng/mL

** <150 pg/mL

Correlation

Author, Year: Clarke, 1998 | Ref ID: 622 | Vitamins: Folate, B12
Objective: Hcy (Folate, B12, MTHFR) and AD

Study characteristics | | Population | | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS (with autopsy in some) Longitudinal | Age*: | All 73.2+/-8.6 | Autopsy 76.6+/-8.0 | 72.8+/-8.8 | Cases: Cognitive dysfunction, referred to Oxford Project to Investigate Memory and Ageing. Histologically confirmed at autopsy (n=76) or clinical diagnosis of probable or possible AD (n=88) | Cases: Age <55 y, no blood sample available | AD: | Histology at autopsy (CERAD criteria) or NINDS-ADRDA
| Comparative | %Male: | 39% | 37% | 43%
| Retrospective | Race: | nd | nd | nd
Country: | UK | CAMCOG: | 55.2 | 45.1 | 97.8 | Controls: Elderly volunteer controls without symptoms of memory impairment (17 of whom were patients' relatives) | Controls:
Setting: | Clinic | MMSE | 16.2 | 12.8 | 28.5
Funding: Pharmaceutical
Comments: Subset of subjects analyzed by Refsum 2003 Ref ID 2661

* Age at time of laboratory testing, regardless of when diagnosis made (ie, autopsy)

CAMCOG, Cambridge Cognitive Examination, maximum score 107

MMSE, Mini-Mental Status Examination, maximum score 30

Predictor(s): (eg, B vit level) | | Outcome(s): AD vs non-AD | Definition: | | Total | Population of interest | Control
Serum Folate* | nmol/L | | | N enrolled: | 272 | 164 | 108
RBC Folate* | nmol/L | Medial temporal lobe CT | | N analyzed: | 272 | 164 | 108
Serum B12** | pmol/L
(Serum Hcy | μmol/L)
(ApoE ε4 allele | frequency)
(MTHFR homozygous mutant | frequency) | | | Drop-outs (%):
Comments:

* Microbiological assay. No data on normal range.

** Radioimmunoassay. No data on normal range.

Other predictors/outcomes reported:
Follow-up duration (if applicable): | XS and 4 years
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 2

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Serum | Folate | nmol/L | p | RBC | Folate | nmol/L | p | Serum | B12 | Pmol/L
| | Mean | SD | r= | | Mean | SD | r= | | Mean | SD | r=
AD (all) | 164 | 17.6 | 10.7 | | <0.001 | 866 | 446 | | <0.05 | 236 | 112 | | NS
AD (subset w/histology) | 76 | 15.2 | 9.5 | | <0.001 | 737 | 386 | | <0.001 | 215 | 79 | | <0.05
Healthy controls | 108 | 22.9 | 10.0 | | — | 991 | 407 | | — | 253 | 100 | | —

Description of (Sub-) Groups | N | Clinically Diagnosed AD | | | | N | Histologically confirmed AD
| | OR (Adj 1*) | | OR (Adj 2*) | | | OR (Adj 1*) | | OR (Adj 2*)
Serum Folate >24.2 nmol/L | 272 | 1 | | 1 | | 184 | 1 | | 1
Serum Folate 17.2–24.2 nmol/L | | 0.8 | (0.5–1.4) | 0.7 | (0.4–1.5) | | 0.6 | (0.2–1.6) | 0.4 | (0.1–1.5)
Serum Folate <17.2 nmol/L | | 2.5 | (1.7–3.8) | 2.3 | (1.4–3.8) | | 5.0 | (3.1–8.2) | 3.3 | (1.8–6.3)
Serum B12 >280 pmol/L | 272 | 1 | | 1 | | 184 | 1 | | 1
Serum B12 200–280 pmol/L | | 1.3 | (0.8–2.0) | 1.7 | (1.0–3.0) | | 2.1 | (1.2–3.6) | 5.6 | (2.6–11.9)
Serum B12 <200 pmol/L | | 1.4 | (0.9–2.2) | 1.4 | (0.8–2.5) | | 1.8 | (1.0–3.2) | 4.3 | (2.1–8.8)
| | | | | | | | | OR (Adj 2+Hcy**)
Serum Folate <17.2 nmol/L | | | | | | | | | 1.6 | (0.8–3.2)
Serum B12 <200 pmol/L | | | | | | | | | 2.2 | (0.8–5.2)

* Adj 1, adjusted for age and sex; Adj 2, adjusted for age, sex, smoking, social class, and ApoE ε4.

** Addition of Hcy to multivariate model

Outcome(s): | Results (Text)
AD Diagnosis | 60% of patients with DAT and 76% with histologically confirmed AD had serum folate concentrations in the bottom 1/3 of the control distribution
Longitudinal | Non-significant trend toward association between both serum folate and B12 at first visit and disease progression, as assessed by thinning medial temporal lobes
CT scan of age-corrected minimum thickness of the Medial Temporal Lobes (annual × 4 yr)

Correlation

Author, Year: Crystal, 1994 | Ref ID: 695 | Vitamins: B12
Objective: Longitudinal association between low B12 and cognitive dysfunction

Study characteristics | | Population | | | Inclusion criteria | Exclusion criteria | Definitions
Study design | Longitudinal | Age: | | (75–85) | Cases: Age 75–85 y, residing in the community, healthy, cognitively intact. | Cases: | AD: | DSM-III, NINCDS-ADRDA
| Non-comparative | %Male: | nd
| Prospective | Race: | nd | | | | PD:
Country: | US | Other: | | | Controls: | Controls: | VascDz:
Setting: | Community | | | | | | Other:
Funding: Government
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest
SerumVitaminB12* | pg/mL | Fuld Object Memory Evaluation (FOME) | test of recent memory | N enrolled: | | nd
| | Blessed Test of Information, Memory and Concentration (BIMC) | | N analyzed: | | 410
| | | | Drop-outs (%):
Comments:

* Corning RIA: Normal geometric mean 458 (95% CI 171, 953) pg/mL

Other predictors/outcomes reported:
Follow-up duration (if applicable): | 5 years
Reasons for drop out (if applicable):
Limitations: | Incomplete description of study sample, tests, or results
Quality (A/B/C): C | Applicability (1/2/3): 3

Outcome(s): | Results (Text)

Correlation of Predictors with Outcomes (Baseline)

Description of (Sub-) Groups | N | FOME | (nd) | | p | BIMC | (nd) | | p
| | Mean | | r= | | Mean | | r=
Serum Vit B12 <150 pg/mL | 22 | 7.10 | | 0.01 | NS | 2.23 | | -0.03 | NS
Serum Vit B12 >150 pg/mL | 388 | 7.40 | | | | 2.46

Correlation of Predictors with Outcomes (At time of diagnosis of AD vs. Baseline all)

Description of (Sub-) Groups | N | Serum | B12 | pg/mL | p
| | Mean
AD (time of diagnosis) | 19 | 551 | | | NS
Cognitively intact (baseline, all subjects) | 410 | 558

Correlation of Predictors with Outcomes (Longitudinal)

Description of (Sub-) Groups | N | AD** | | p | All Dementia** | | p
| | n | % | | n | %
Serum Vit B12 <150 pg/mL (baseline)* | 22 | 3 | 4.5% | NS | 1 | 13.6% | NS
Serum Vit B12 >150 pg/mL (baseline) | 388 | 29 | 7.5% | | 57 | 14.7%

* Treated by private physicians for B12 deficiency.

** Incidence over 5 years.

Correlation

Author, Year: Duthie, 2002 | Ref ID: 10003 | Vitamins: Folate and B12
Objective: The potential contributions of blood Vit B12, folate, and Hcy concentrations to individual differences in life cognitive variance after taking childhood IQ into account

Study characteristics | | Population | ABC 21 | ABC 36 | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS/Longitudinal | Age: | 77 | 62 | Cases: Invited to participate the 2 cohorts of survivors of Aberdeen 1921 Birth cohort and Aberdeen 1936 Birth cohort in 2 assessments during the years 1998-1999(wave 1) and the second in 1999-2000 (wave 2) | Cases: Blood b12 conc was 664 pmol/L and blood folate >59nmol/L | AD:
| Comparative | %Male: | 50% | ND
| Retrospective | Race: | Probably white | Probably white | | | PD:
Country: | UK | Other: | | | Controls: | Controls: | VascDz:
Setting: | Academic setting | | | | | | Other: Dementia | <24 suggestive of mild dementia
| | | | | | | | <20 indicate dementia
Funding: Private non industry and Gov
Comments: 2 cohorts with different birth yrs ie survivors of Aberdeen 1921 Birth cohort and Aberdeen 1936 Birth cohort were used for the study

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest ABC21 | ABC36
Vit B12 | pmol/L | MMSE | <24 suggestive of mild dementia | N enrolled: | 335 | 186 | 148
| | | <20 indicate dementia
Folate | nmol/L | | | N analyzed: | 309 | 165 | 144
| | | | Drop-outs (%): | 1%
Comments:

57 Plasma and RBC folate and vit B12 were measured using Simultrac Radioassay kit vit B12 Co/folic acid ^125^I

Other predictors/outcomes reported: | Predictors: National adult reading test (NART); Ravens progressive matrices (RPM); Auditory verbal learning test (AVLT); Block design (BD); Digital symbol subtest (DS)
| Outcomes: Homocysteine
Follow-up duration (if applicable): | ND
Reasons for drop out (if applicable): | 3 patients were removed from the analysis because their blood level for vitamins met the exclusion criteria
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 3

Correlation of Predictors with Outcomes (cross-sectional studies) (MMSE vs vit)

Description of (Sub-) Groups | N | Sr | B 12 | pmol/L | p | Pl | Folate | nmol/L | p | RBC | Folate | μg/g protein | p | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | CI | r= | | Mean | CI | r= | | Mean | CI | r= | | Mean | SE/SD | r=
ABC21 | 165 | 280.0 | 263.5, 296.1 | 0.24 | <0.01 | 16.8 | 15.6, 17.9 | 0.2 | <0.05 | 1.04 | 0.98, 1.1 | 0.13 | NS
ABC36 | 144 | 291.5 | 275.9, 296.1 | 0.03 | NS | 17.7 | 16.3, 19.0 | 0 | NS | 0.98 | 0.92, 1.04 | -0.03 | NS

Correlation of Predictors with Outcomes (cross-sectional studies)* (MMSE vs vit)

Description of (Sub-) Groups | N | Sr | B 12 | pmol/L | p | Pl | Folate | nmol/L | p | RBC | Folate | μg/g protein | p | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | CI | r= | | Mean | CI | r= | | Mean | CI | r= | | Mean | SE/SD | r=
ABC21 | 165 | 280.0 | 263.5, 296.1 | +0.23 | <0.01 | 16.8 | 15.6, 17.9 | 0.19 | <0.05 | 1.04 | 0.98, 1.1 | 0.09 | NS
ABC36 | 144 | 291.5 | 275.9, 296.1 | +0.05 | NS | 17.7 | 16.3, 19.0 | 0.02 | NS | 0.98 | 0.92, 1.04 | -0.046 | NS

* adjusted for childhood intelligence quotient

Correlation of Predictors with Outcomes (cross-sectional studies) (BD vs vit)

Description of (Sub-) Groups | N | Sr | B 12 | pmol/L | p | Pl | Folate | nmol/L | p | RBC | Folate | μg/g protein | p | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | CI | r= | | Mean | CI | r= | | Mean | CI | r= | | Mean | SE/SD | r=
ABC21 | 165 | 280.0 | 263.5, 296.1 | -0.06 | NS | 16.8 | 15.6, 17.9 | +0.06 | NS | 1.04 | 0.98, 1.1 | 0.02 | NS
ABC36 | 144 | 291.5 | 275.9, 296.1 | +0.03 | NS | 17.7 | 16.3, 19.0 | 0.24 | <0.05 | 0.98 | 0.92, 1.04 | 0.08 | NS

Correlation of Predictors with Outcomes (cross-sectional studies)* (BD vs vit)

Description of (Sub-) Groups | N | Sr | B 12 | pmol/L | p | Pl | Folate | nmol/L | p | RBC | Folate | μg/g protein | p | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | CI | r= | | Mean | CI | r= | | Mean | CI | r= | | Mean | SE/SD | r=
ABC21 | 165 | 280.0 | 263.5, 296.1 | -0.07 | NS | 16.8 | 15.6, 17.9 | 0.07 | NS | 1.04 | 0.98, 1.1 | 0.01 | NS
ABC36 | 144 | 291.5 | 275.9, 296.1 | 0.097 | NS | 17.7 | 16.3, 19.0 | 0.24 | <0.01 | 0.98 | 0.92, 1.04 | 0.19 | NS

* adjusted for childhood intelligence quotient

Correlation of Predictors with Outcomes (cross-sectional studies) (DS vs vit)

Description of (Sub-) Groups | N | Sr | B 12 | pmol/L | p | Pl | Folate | nmol/L | p | RBC | Folate | μg/g protein | p | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | CI | r= | | Mean | CI | r= | | Mean | CI | r= | | Mean | SE/SD | r=
ABC21 | 165 | 280.0 | 263.5, 296.1 | 0.03 | NS | 16.8 | 15.6, 17.9 | 0.19 | <0.05 | 1.04 | 0.98, 1.1 | 0.19 | <0.05
ABC36 | 144 | 291.5 | 275.9, 296.1 | 0.10 | NS | 17.7 | 16.3, 19.0 | 0.14 | NS | 0.98 | 0.92, 1.04 | 0.08 | NS

Correlation of Predictors with Outcomes (cross-sectional studies)* (DS vs vit)

Description of (Sub-) Groups | N | Sr | B 12 | pmol/L | p | Pl | Folate | nmol/L | p | RBC | Folate | μg/g protein | p | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | CI | r= | | Mean | CI | r= | | Mean | CI | r= | | Mean | SE/SD | r=
ABC21 | 165 | 280.0 | 263.5, 296.1 | -0.03 | NS | 16.8 | 15.6, 17.9 | 0.19 | <0.05 | 1.04 | 0.98, 1.1 | 0.09 | NS
ABC36 | 144 | 291.5 | 275.9, 296.1 | 0.159 | NS | 17.7 | 16.3, 19.0 | 0.111 | NS | 0.98 | 0.92, 1.04 | 0.03 | NS

* adjusted for childhood intelligence quotient

Correlation

Author, Year: Engelborghs, 2004 | Ref ID: 918 | Vitamins: B12, folate
Objective: To test for possible correlations of decreased sr vit B12 and red cell folate levels with degree of cognitive impairment and extent of behavioral and psychological signs and symptoms of dementia among AD and FTD patients

Study characteristics | | Population | | | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 79±7 | 69±11 | Cases: Consecutively hospitalized patients for diagnostic work up of dementia | Cases: Patients on vitamin supplementation, alcohol abuse, and artificially fed | AD: | Based on NINCDS-ADRDA criteria and DSM-IV
| Comparative | %Male: | 48% | 50%
| Prospective | Race: | ND | ND | | | PD:
Country: | Belgium | Other:Disease duration | 4±3 | 6±4 P=<0.001 | Controls: Same as above | Controls: Same as above | VascDz:
Setting: | Academic hospital | MMSE score | 12.7±6.9 | 16.3±8.3 P=0.02 | | | Other: FTD | MMSE, Hierarchic dementia scale, global deterioration scale
Funding: University and private non-industry
Comments: Staging of dementia done on global deterioration scale

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control (FTD)
Sr vit B12 | 193–982 pg/mL | Hierarchic Dementia scale | 0–10 | N enrolled: | 180 | 152 | 28
Red cell folate | 93–641 ng/mL | MMSE | 0–30 | N analyzed: | 180 | 152 | 28
| | | | Drop-outs (%): | 0
Comments: Vit B12 and folate assessed by use of solid phase radioassay kits

Other predictors/outcomes reported: | Behavioral testing (Behave AD; cohen Mansfield Agitation; verbally agitated behavior; cornell scale for depression)
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Compared to fronto temporal dementia and only significant correlations available
Quality (A/B/C): C | Applicability (1/2/3): 2

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Sr | B 12 vit | pg/mL | p | Red cell | Folate | ng/mL | p
| | Mean | SD | r= | | Mean | SE/SD | r=
AD-HDS | 152 | 382.8 | 257.8 | ND | NS | 245.5 | 197.5 | 0.205 | 0.03
FTD-HDS | 28 | 316.6 | 120.0 | 0.538 | 0.014 | 277.2 | 195.2 | ND | NS
AD-MMSE | 152 | | | ND | NS | | | ND | NS
FTD-MMSE | 28 | | | ND | NS | | | 0.443 | 0.02

Correlation

Author, Year: Garcia, 2004 | Ref ID: 1063 | Vitamins: B12, Folate
Objective: Association with cognitive function in elderly

Study characteristics | | Population | | | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 73.0 | (4.9) | Cases: Age ≥65 y, Independent-living, attend senior community center | Cases: Oral B12 >37.5 μg/day, Parenteral B12, history of ileal/gastric surgery, Serum Creatinine >130 mmol/L, neurological disease (eg, dementia, stroke, severe head trauma, PD), depression, MMSE<24, hospitalization within prior 3 months, any acute medical condition | AD:
| Non-comparative | %Male: | 25%
| Prospective | Race: | nd | | | | PD:
Country: | Canada | MMSE: | 28.3 | (1.52) | Controls: | Controls: | VascDz:
Setting: | Community | | | | | | Other:
Funding: Private non-profit
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest
Serum Vit B12* | pmol/L | Mattis DRS | screening for dementia, includes subtests for attention, initiation, perseveration, construction, conceptualization, and memory | N enrolled: | 281 | 281
(RBC Folate** | nmol/L) | Stroop Neuropsychological Screening Inventory | | N analyzed: | 281 | 281
| | California Verbal Learning Test (CVLT) | Verbal learning characteristics in 5 categories: recall measures, learning characteristics, recall errors, recognition measures, and contrast measures.
| | | Each metric analyzed separately. Appears that for each outcome, the metric that was most strongly correlated was marked as “Factor 1” and analyzed alone. Each outcome thus analyzed against different metrics of the CVLT.
| | | | Drop-outs (%):
Comments:

* Standard radioimmunoassay. Normal range 165–740 pmol/L

** Standard radioimmunoassay. Normal range 200–1300 nmol/L. Measured, but no analyses reported.

Other predictors/outcomes reported: | Methylcitric acid, MMA, Hcy
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Analyses opaque
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text)
CVLT | Analysis unclear and very difficult to interpret. Authors conclude that Vitamin B12 levels did not significantly correlate after multivariate analysis with the psychometric measures

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Stroop | (Max 112) | | p | Mattis | (Max 144) | | p
| | Mean | SD | r= | | Mean | SD | r=
Low Vit B12 | 44 | 83.4 | 21.4 | | NS | 138.8 | 4.7 | | NS
Normal Vit B12 | 237 | 82.7 | 18.8 | | | 139.0 | 4.2

Correlation

Author, Year: Gold, 1995 | Ref ID: 1119 | Vitamins: Thiamine
Objective: Thiamine levels among patients at memory clinic

Study characteristics | | Population* | | Controls** | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 77.8+/-7.7 | 74.9+/-6.4 | Cases: Under evaluation for cognitive impairment | Cases: | AD: | NINCDS-ADRDA
| Non-comparative | %Male: | 18% | 47%
| Prospective | Race: | nd | nd | | | PD:
Country: | US | Other: | | | Controls: | Controls: | VascDz:
Setting: | Clinic | | | | | | Other:
Funding: nd

* Diagnosed with Senile dementia of Alzheimer's type (SDAT)

** Non-SDAT

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Plasma thiamine* | ng/mL | MMSE | | N enrolled: | | nd
RBC thiamine* | ng/mL | Diagnosis of AD | | N analyzed: | | 34
| | | | Drop-outs (%):
Comments:

* Microbiologic assay (Kloeckera apiculata). Thiamine deficient defined as below age-matched normal range.

Plasma: Normal mean (range): Age 61–80: 12.0 (8–26); Age 81+: 11.0 (10–12.6) ng/mL

RBC: Normal mean (range): Age 61–80: 146.0 (89–205); Age 81+: 140.0 (131–163) ng/mL

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Authors note possibility that some “non-SDAT” patients may also have AD (in addition to other causes of dementia). Definition of low thiamine vague and age-dependent in a non-consistent manner (normal mean lower in elderly, but lower end of range higher).
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text)
MMSE | There was no significant difference in MMSE scores between patients with probably SDAT with low plasma thiamine levels and those with normal plasma thiamine levels (P=0.11).

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Plasma | B1 | ng/mL | p | Plasma | B1 | Low* | p | RBC | B1 | ng/mL | p | RBC | B1 | Low* | p
| | Mean | SD | | | n | % | | | Mean | SD | | | n | %
SDAT | 17 | 7.5 | 4.1 | | 0.002 | 11 | 65% | | <0.001 | 149.9 | 34.6 | | 0.07 | 3 | 18% | | 0.70
Non-SDAT | 17 | 12.6 | 5.4 | | | 2 | 12% | | | 168.0 | 47.8 | | | 0 | 0%

* Age 61–80: <8 ng/mL; Age 81+: <10 ng/mL

** Age 61–80: <89 ng/mL; Age 81+: <131 ng/mL

Correlation

Author, Year: Gold, 1998 | Ref ID: 1120 | Vitamins: Thiamine
Objective: To explore the extent of thiamine deficiency in neurodegenerative by determining the plasma and RBC thiamine levels in PD patients and comparing the results to a previous group of probable AD patients (Gold et al 1995)

Study characteristics | | Population | p-AD | PD | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 77.8+/-7.7 | 71.3 (8.7) | Cases: AD recruited from Memory Disorders Clinic who were ambulatory and were living at home, either independently or with a dedicated caregiver. | Cases: Patients with any h/o gastric, digestive diseases, of gastric or intestinal resections, or of malabsorption syndrome | AD: | NINCDS/ADRDA criteria for probable AD
| Comparative | %Male: | 18% | 61% | PD patients recruited from Movement Disorders Clinic. The inclusion criteria were age >50 and a diagnosis of Parkinson's disease. All patients were receiving dopaminergic meds and had significant clinical responses
| Retrospective | Race: | nd | nd | | | PD: | Clinically accepted criteria 2/3 cardinal features: tremor, bradykinesia, or rigidity
Country: | US | Other: | | | Controls: None | Controls: | VascDz:
Setting: | Academic hospital | | | | | | Other:
Funding: nd
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | | Control
| | | | | | AD | PD
Plasma thiamine* | ng/mL | Levels in AD patients | | N enrolled: | 50 | 17 | 33
Erythrocyte thiamine* | ng/mL | Levels in AD patients | | N analyzed: | 50 | 17 | 33
| | | | Drop-outs (%): | nd
Comments:

* Non fasting levels assessed by using a bioassay (Lactobacilli agar)

Other predictors/outcomes reported: | None
Follow-up duration (if applicable): | A group of PD patients compared to those with AD from a different year
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 1

Outcome(s): | Results (Text)
Plasma thiamine levels | Statistical analysis demonstrated that patients with pAD had sig lower raw plasma thiamine levels (p<0.001) and lower z-score plasma thiamine levels (p<0.01) than patients with PD.
RBC thiamine levels | No significant differences were noted in the raw RBC thiamine levels or z score RBC thiamine levels between two groups of patients.
| A sig higher number of AD patients were plasma thiamine deficient than PD patients (p<0.001)
| No correlation between RBC and plasma thiamine levels for either group of patients

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Pl | Thiamine | ng/mL | p | RBC | B1 | ng/mL | p | | MMSE scores | 0–30 | | Pl | B1 deficiency patients | ng/mL | p
| | Mean | SD | r= | | Mean | SD | r= | | Mean | SD | r= | P | Mean | SE/SD | Prevalence
AD | 17 | 7.5 | 4.1 | | <0.001 | 149.9 | 34.6 | | NS | 17.6 | 7.7 | | <0.001 | | | 65%
PD | 33 | 11.06 | 4.08 | | | 146.8 | 43.1 | | | 26.8 | 4.1 | | | | | 9%

Correlation

Author, Year: Goodwin, 1983 | Ref ID: 1129 | Vitamins: B1, riboflavin, B12, B6, folate
Objective: To examine the hypothesis that subclinical malnutrition may be associated with age-related changes in cognitive function

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 72 (60–94) | Ambulatory and living independently and recruited from Albuquerque area in early 1979 with 1) age of 60 yrs or older 2) no prescription medication or daily nonprescription meds 3) no known serious medical diagnoses eg cancer, aortic stenosis, diabetes or TIA while patients with osteoarthritis or cataracts included as long as they were not receiving medications | Those with serious medical diagnosis and on prescription meds (n=24); incomplete dietary intake, vitamin levels, or cognitive assessment (n=11); subjects died before administration of the cognitive tests (n=7) | AD:
| Non-comparative | %Male: | 46%
| Prospective | Race: | ND | | | PD:
Country: | US | Other: | 85% finished high school and 49% finished college | | | VascDz:
Setting: | Academic hospital | | | | | Other:
Funding: Gov and Private foundation | | | | | | healthy
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Folate, thiamine, riboflavin, pyridoxine, and vitamin B12 nutrient intake | Dietary intakes were measured by 3-day food record, weighting all food items on a portable scale. | Cognitive tests | Halstead-Reitan categories test | N enrolled: | 304 | 304
Folate, thiamine, riboflavin, pyridoxine, and vitamin B12 blood levels | Fasting blood samples. | | Wechsler verbal memory test | N analyzed: | 260 | 260
| The assessment of thiamine and riboflavin was determined by a functional assay; ie, transketolase and glutathione reductase, respectively. | | | Drop-outs (%): | 14%
| Plasma levels of folate (RBC) and vitamin B12 were determined by competitive binding radioassays.
Dietary intake categories | Bottom 5%, bottom 10%; top 90%
Comments: | Halstead Reitan categories test was a nonverbal automated test of abstract thinking and problem solving ability and sensitive indicator for minimal changes in mental status
| All correlations were controlling for age and sex of the subjects.

Other predictors/outcomes reported: | Protein intake, vitamin C intake and blood levels
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Data analyze for completers only. No means of intakes or blood levels were reported.
Quality (A/B/C): B | Applicability (1/2/3): 2

Outcome(s): | Results (Text)
Mean scores of halstead Reitan Categories test | There was a trend for those subjects in the bottom 5% or 10% of dietary intake of all nutrients to do poorly on the test compared with the rest of the population except for folate
Mean scores of Wechsler Memory test | There was a trend for those subjects in the bottom 5% or 10% of dietary intake of all nutrients to do poorly on the test compared with the 90% of the population
Mean scores of halstead Reitan Categories test | There was a trend for those subjects in the bottom 5% or 10% of blood levels of specific nutrients riboflavin, vit B12 and folic acid to do poorly on the test compared with the rest of the population
Mean scores of Wechsler Memory test | Statistically significant deficiencies in performance were seen in those with low levels of vit B12

Correlation of dietary intake levels of B vitamins with cognitive function (cross-sectional studies)

Description of (Sub-) Groups | N | Folate | p | Thiamine | p | Riboflavin | p | Pyridoxine | p | Vit B12 | p
| | r= | | r= | | r= | | r= | | r=
Halstead Reitan Categories test | 260 | .00 | NS | -.02 | NS | .05 | NS | -.04 | NS | -.04 | NS
Wechsler verbal memory test | 260 | -.06 | NS | -.02 | NS | .02 | NS | -.02 | NS | -.02 | NS

Correlation of blood levels of B vitamins with cognitive function (cross-sectional studies)

Description of (Sub-) Groups | N | Sr | Folate | ND | p | Sr | Thiamine | ND | p | Sr | Riboflavin | ND | | Sr | B 12 | ND | p
| | Mean | SE/SD | r= | | Mean | SE/SD | r= | | Mean | SE/SD | r= | | Mean | SE/SD | r=
Halstead Reitan Categories test | 260 | | | 0.08 | NS | | | .02 | NS | | | .02 | NS | | | .02 | NS
Wechsler verbal memory test | 260 | | | -.03 | NS | | | -.04 | NS | | | .14 | <0.05* | | | .00 | NS

* Remained sig in a multivariate analysis controlling for age and sex of the subjects

Correlation

Author, Year: Gottfries, 2001 | Ref ID: 1145 | Vitamins: B12, Folate
Objective: Correlation of B vitamins (etc.) with cognitive impairment

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 70.4 | Cases: Ambulatory, age ≥50 yr, complaining about cognitive disturbances in an outpatient memory clinic. | Cases: Plasma B12 >600 pmol/L, Plasma folate > 30 nmol/L, or Serum creatinine >100 nmol/L (to exclude those taking supplements or with insufficient kidney excretion, thus elevating homocysteine) | Alzheimer Type of Dementia (DAT): | DSM-IV, NINCDS-ADRDA
| Comparative | %Male: | 46%
| Prospective | Race: | nd | | | Mild Cognitive Impairment: | Cognitive impairment not severe enough to meet criteria for dementia
Country: | Sweden | Other: | | Controls: | Controls: | Vascular Dementia (VAD): | NINDS-AIREN
Setting: | Outpatient memory unit | | | | | Subjective Memory Complaints: | Complaints were not confirmed by psychological testing
Funding: nd
Comments:

VAD = vascular dementia

Predictor(s): (eg, B vit level) | | Outcome(s): 4 diagnostic groups | Definition: As defined above | | Total | Population of interest | Control
Plasma B12* | pmol/L | | | N enrolled:
CSF B12** | pmol/L | | | N analyzed:
CSF B12/Blood B12*** | x1000
Plasma Folate**** | nmol/L
Blood Folate***** | nmol/L | | | Drop-outs (%):
Comments:

* No data on measurement method. Normal range 150–700 pmol/L

** No data on measurement method. Normal range is unknown.

*** Normal range is unknown

**** No data on measurement method. Normal range 6–39 nmol/L

***** No data on measurement method. Normal range 140–380 nmol/L

Otherpredictors/outcomes reported: | Serum and CSF Homocysteine, Serum and CSF MMA, CSF Tau protein, CSF/Serum albumin ratio, Brain imaging pathology, vascular risk factors, EEG
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Reported values are not adjusted for potential confounders. Numbers of subjects in each analysis unclear
Quality (A/B/C): C | Applicability (1/2/3): 3

Outcome(s): | Results (Text)

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N* | Plasma | B12 | pmol/L | p | Plasma | B12 | p | CSF | B12 | pmol/L | p | CSF/Plasma | B12 | p
| | Mean | SD | | | % <150 pmol/L | | | Mean | SD | | | Mean | SD
DAT | ≤43 | 355.8 | 130.9 | | NS | 0% | | NS | 13.9 | 10.0 | | NS | 39.8 | 22.5 | NS
Mild Cog Impair | ≤32 | 295.8 | 93.6 | | | 6.3% | | | 11.3 | 5.8 | | | 40.1 | 19.9
VAD | ≤14 | 272.2 | 105.5 | | | 7.7% | | | 10.8 | 6.3 | | | 39.9 | 18.8
Subj Memory Compl | ≤12 | 330.2 | 113.3 | | | 8.3% | | | 14.4 | 6.4 | | | 49.8** | 28.2

* 101 in total cohort (43+32+14+12). However, Plasma B12 had N=99; CSF B12 had N=80.

** “Numerically higher [than other groups], which would suggest a better transport of vitamin B12 into the brain in this group.”

Description of (Sub-) Groups | N* | Plasma | Folate | nmol/L | p | Plasma | Folate | p | Blood | Folate | nmol/L | p | Blood | Folate | p
| | Mean | SD | | | % <6 nmol/L | | | Mean | SD | | | % <140 nmol/L
DAT | ≤43 | 12.2 | 4.5 | | NS | 0% | | NS | 237.5 | 78.7 | | NS | 5.9% | | NS
Mild Cog Impair | ≤32 | 14.1 | 6.9 | | | 6.3% | | | 253.8 | 90.0 | | | 4.2%
VAD | ≤14 | 11.4 | 4.6 | | | 7.7% | | | 267.0 | 145.5 | | | 0%
Subj Memory Compl | ≤12 | 12.7 | 5.1 | | | 0% | | | 282.5 | 86.5 | | | 0%

* 101 in total cohort (43+32+14+12). However, Plasma Folate had N=98 and Blood Folate had N=74.

Correlation

Author, Year: Haller, 1996 | Ref ID: 1239 | Vitamins: Folate and Cobalamin
Objective: Assessment of the mental health of the European elderly and its correlations with micronutrient plasma levels, education and ability to carry out activities of daily living

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | | | Cases: Randomized sample of both sexes born in the period 1913 to 1918. | Cases: | AD:
| Non-comparative | %Male: | 49%
| Prospective | Race: | | | | | PD:
Country: | 9 European countries | Other: | | | Controls: | Controls: | VascDz:
Setting: | | | | | | | Other:
Funding:
Comments:

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
folate | MMSE score | | N enrolled: | 885 | 885
cobalamin | MMSE score | | N analyzed: | 885 | 885
| | | Drop-outs (%):
Comments:

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: method of randomization not stated
Quality (A/B/C): C | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
| There were highly significant but weak correlations between the total MMSE scores and the coblamin and folate plasma levels.

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | (Sr/CSF) | folate | (unit) | p | (Sr/CSF) | cobalamin | (unit) | p
| | Mean | SE/SD | r= | | Mean | SE/SD | r=
MMSE overall | 885 | | | 0.103 | <0.01 | | | 0.125 | <0.001
MMSE men | 433 | | | ND | | | | 0.161 | <0.001
MMSE women | 452 | | | 0.113 | <0.05 | | | ND

Correlation

Author, Year: Jelicic, 2002 | Ref ID: 1498 | Vitamins: Vitamin B12 and folate
Objective: To examine the effects of low levels of vitamin B12 and folate in older adults on speed of information processing and memory

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 68.7 | | Cases: Non-demented older people who underwent blood tests | Cases: | AD:
| Comparative | %Male: | 47%
| Retrospective | Race: | | | | | PD:
Country: | The Netherlands | Other: | | | Controls: | Controls: | VascDz:
Setting: | Genral population | | | | | | Other:
Funding: Dutch Ministry of Health, Welfare and Sports
Comments:

Predictor(s): (eg, B vit level) | Outcome(s): Memory and speed of information processing | Definition: | | Total | Population of interest | Control
Group 1: normal B12 & folate levels | | | N enrolled: | 698
Group 2: normal B12 & low folate levels | | | N analyzed: | 698
Group 3: low B12 & normal folate | | | Drop-outs (%): | 0
Group 4: low B12 & folate
Comments: There were differences between the study groups with respect to age and education.

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 2

Outcome(s): | Results (Text): ANOVA was used to determine whether the 4 groups differed with regard to cognitive performance using age and education as covariates.
| 1. No significant differences in memory performance were found.
| 2. Borderline significant differences (p=0.087) between the 4 groups with respect to speed of information processing were found.
| 3. Post hoc analyses using ANOVA with age and education as covariates showed that Group 1 (normal B12 & folate) exhibited better performance on the coding task than group 3 (low B12 only), p<0.05.
| 4. The other post hoc analyses were not significant.
| 5. ANOVA with age and education as covariates revealed that particpants with normal B12 outperformed those with low B12 on coding task.

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Memory score | | (unit) | p | Speed of information processing | | (unit) | p
| | Mean | SD | r= | | Mean | SD | r=
Group 1: normal B12 & folate | 469 | 19.9 | 6.1 | | | 38.8 | 11.7
Group 2: normal B12, low folate | 100 | 18.7 | 5.5 | | | 36.1 | 9.7
Group 3: low B12, normal folate | 98 | 18.6 | 5.6 | | | 34.1 | 11.1
Group 4: low B12 & folate | 31 | 16.9 | 4.2 | | | 30.3 | 10.8

Correlation

Author, Year: Jimenez-Jimenez, 1999 | Ref ID: 1507 | Vitamins: thiamine
Objective: To assess the lumbar CSF levels of thiamine and their phosphate esters in pts with PD compared with a control population

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 64 | 63 | Cases: PD | Cases: Vitamin in last 6 mo, ETOH >80 g/day in last 6 mo, previous hx of chronic liver disease, CRF, gastrectomy, pancreatic diseases, malabsorption, atypical diets, undernutrition, severe systemic disease | AD:
| Comparative | %Male: | 58 | 40
| Retrospective | Race: | ND | ND | | | PD: Diagnosed; details not provided
Country: | Spain | Other: | | | Controls: ‘healthy’: suspected subarachnoid hemorrhage, psuedotumor cerebri, oculomotor palsies or other neurological dx that required LPs | Controls: Same as above | VascDz:
Setting: | 2 urban hospitals | | | | | | Other:
Funding: Comunidad de Madrid & Fundacion Neurociencias y Envejecimiento
Comments: 7/24 pts with PD untreated; control population had suspected neurological problems other than PD

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
Free and total thiamine | | | N enrolled: | 64 | 24 | 40
Thiamine-diphosphate | | | N analyzed: | 64 | 24 | 40
Thiamine-monophosphate | | | Drop-outs (%): | 0
Comments:

Analysis of thiamine by ion-pair reversed phase HPLC according to Bettendorff et al

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: control group not healthy
Quality (A/B/C): C | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
| 1 The mean CSF levels of thiamine-diphosphate, thiamine-monophosphate, and total thiamine of PD pts did not differ significantly from those of controls, although free CSF thiamine levels were significantly lower in the PD patient group.; 2 PD pts treated with levodopa had significantly higher CSF thiamine-diphosphate and total thiamine than those not treated with this drug.; 3 No significant correlation in PD pts between the CSF thiamine (in all their forms) and age, age at onset of PD, duration of PD, scores of the Activities of Daily Living and motor examination, and the Hoehn and Yahr staging.; 4 There was no correlation between CSF thiamine levels and the analyzed clinical features of PD.

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | CSF | Thiamine-diphosphate (nmol/L | p | CSF | Thiamine-monophosphate (nmol/L) | p | CSF | Free thiamine (nmol/L) | p | CSF | Total thiamine (nmol/L) | p
| | Mean | SD | | Mean | SD | | Mean | SD | | Mean | SD
PD | 24 | 3.9 | 3.0 | | 4.3 | 3.3 | | 0.9 | 1.3 | | 9.1 | 6.4
Control | 40 | 3.1 | 2.3 | | 4.3 | 2.9 | | 1.9 | 1.4 | <0.01 | 9.3 | 5.1
PD (+)L-DOPA | 15 | 5.1 | 3.1 | | 5.2 | 3.6 | <0.01 | 1.1 | 1.6 | | 11.5 | 6.7 | <0.01
PD (-)L-DOPA | 9 | 2.0 | 1.5 | | 2.8 | 2.1 | | 0.4 | 0.3 | | 5.2 | 3.7

Correlation

Author, Year: Jones, 2002 | Ref ID: 1533 | Vitamins: B12, folic acid
Objective: To examine the variability in rate of decline during the last 3 yr before the diagnosis of AD could be linked to participant characteristics within demographic, health related, genetic and social domains

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Longitudinal | Age: | ND | | Cases: All inhabitants aged ≥75 yrs and older in the Kungsholmen Parish of Stockholm, Sweden | Cases: | AD: | ND
| Non-comparative | %Male: | ND
| Prospective | Race: | Probably white | | | | PD:
Country: | Sweden | Other: | | | Controls: | Controls: | VascDz:
Setting: | Community based | | | | | | Other:
Funding: ND
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): MMSE (Swedish version) | Definition: 0–30 | | Total | Population of interest | Control
Vit B12 | ND | | | N enrolled: | 230 | 230
Folate | ND | | | N analyzed: | 230 | 230
| | | | Drop-outs (%):
Comments: MMSE (Swedish version) administered both at baseline and at follow-up

Other predictors/outcomes reported: | Demographic factors; disease measures; depression; ApoE genotype
Follow-up duration (if applicable): | 3 yr
Reasons for drop out (if applicable):
Limitations: | Very incomplete description of results
Quality (A/B/C): C | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
Cognitive decline | Vitamin status (B12 and folate) did not precipitate (ie, not associated with) the decline

Correlation

Author, Year: Joosten, 1997 | Ref ID: 1536 | Vitamins: B12, Folate
Objective: B12, Folate, MMA in AD and controls

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS/Longitudinal | Age: | 82.8+/-4.9 | 1. 81.1+/-5.8 2. 79*+/-5.9 | Cases: Age >70 y, admitted to acute geriatric ward, screened in for probable AD | Cases: Vitamin supplement, blood transfusion, life-threatening disease | AD: | DSM-III-R and NINCDS-ADRDA MMSE<21 Hachinski<4
| Comparative | %Male: | 37% | 1. 42% 2. 33%
| Prospective | Race: | nd | nd
Country: | Belgium | Other: | | | Controls:; 1 Age >70 y, admitted to acute geriatric ward, screened out for probable AD, age and sex matched; 2 Age >70 y, healthy, living at home independently | Controls:; 1 Vitamin supplement, blood transfusion, life-threatening disease; 2 Same as 1 + Malignancy, vascular disorder
Setting: | Hospital and Home
Funding: Pharmaceutical
Comments:

* Significantly different than AD (P<0.001)

Predictor(s): (eg, B vit level) | | Outcome(s): AD diagnosis | Definition: | | Total | Population of interest | Control
Serum Vit B12* | ng/L | | | N enrolled: | 151 | 52 | 1. 50 2. 49
Serum Folate** | μg/L | | | N analyzed: | 151 | 52 | 1. 50 2. 49
MMA | nmol/L | | | Drop-outs (%):
Hcy | μmol/L
Comments:

* Amersham, radioimmunoassay. Normal range 140–550 ng/L.

** Amersham, radioimmunoassay. Normal range 2.4–7.2 μg/L.

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): C | Applicability (1/2/3): 2

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Serum | B12 | ng/L | p | Serum | B12 | <139 ng/L | p | Serum | Folate | μg/L | p | Serum | Folate | <2.4 μg/L | p
| | GeoMean | 95%range | r= | | Prevalence | | | | GeoMean | 95%range | r= | | Prevalence
AD | 52 | 284 | (80–999) | | NS | 3.8% | | | NS | 3.5 | (1.3–9.7) | | NS | 21.2% | | | 0.042
Hospitalized, non-AD | 50 | 281 | (89–887) | | | 10% | | | | 4.0 | (1.5–10.9) | | | 14% | | | NS
Healthy | 49 | 284 | (119–673) | | | 6.1% | | | | 3.8 | (1.8–8.2) | | | 6.1% | | | NS

GeoMean, geometric mean

Correlation

Author, Year: Malaguarnera, 2004 | Ref ID: 1972 | Vitamins: Pyridoxal phosphate levels
Objective: To evaluate the relationship between the plasma Hcy levels and the vitamins involved in its metabolism in cognitive disorders

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 72.6 (7.38) | 73.7 (4.2) | Cases: AD patients: all those who presented with progressive cognitive deficit for at least one year | Cases: | AD: | NINCDS-ADRDA criteria and also confirmed by cerebral CT or MRI that showed cortical atrophy and normal aspects of the white matter in all patients
| Comparative | %Male: | 32% | 50% | VascDz: ND
| Prospective | Race: | ND | ND | | | PD:
Country: | Italy | Other: | | | Controls: ND | Controls: | VascDz: | NINDS-AIREN criteria and confirmed radiologically by subcortical lacunaes and/or multiple involvement of the inner white matter
Setting: | Academic hospital | | | | | | Other:
Funding: ND | | | | | | | Normal healthy | Clinically and MMSE score to rule out cognitive impairment
Comments: (B12 and folate not extracted as total n<100)

Predictor(s): (eg, B vit level) | | Outcome(s): Dementia | Definition: AD | | Total | Population of interest* | Control
Pyridoxal phosphate levels | nmol/L | | | N enrolled: | 68 | 22 | 24
| | | | N analyzed: | 68 | 22 | 24
| | | | Drop-outs (%):
Comments: * included only patients with AD and healthy (vascdz n=22 not included)

PLP measured by radio-enzymatic assay

Other predictors/outcomes reported: | Hcy, folate, vit B12, cholesterol, HDL, TG, LDL
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Small N and XS
Quality (A/B/C): C | Applicability (1/2/3): 1

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Sr | PLP | nmol/L | p
| | Mean | SD
AD | 22 | 52.0 | 10.78 | | NS
Healthy controls | 24 | 57.5 | 8.19

Correlation

Author, Year: Mastrogiacoma, 1996 | Ref ID: 2032 | Vitamins: B1
Objective: To evaluate the status of brain thiamine and its phosphate esters in AD

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 73 (2) | 70 (3) | Cases: Tissues from the autopsied brains of confirmed patients with AD | Cases: ND | AD: | Presence of both neuritic plaques and neurofibrillary tangles in both neocortex and hippocampus in the absence of any degenerative process
| Comparative | %Male: | ND | ND
| Retrospective | Race: | ND | ND | | | PD:
Country: | Canada and Belgium | Other: | | | Controls: neurologically and histopathologically normal control subjects matched with respect to age, post mortem status, premortem agonal status, cerebral cortical pH and lactic acid levels | Controls: ND | VascDz:
Setting: | Academic hospital | | | | | | Other:
Funding: Multi Gov funds and student award
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Free non-phosphorylated thiamine | ND | Cerebral cortical levels (temporal, parietal, occipital) | | N enrolled: | 38 | 20 | 18
Total thiamine | ND | | | N analyzed: | 38 | 20 | 18
| | | | Drop-outs (%):
Comments:

Other predictors/outcomes reported: | Thiamine dependent enzymes
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Autopsy study and no correlation with sr levels
Quality (A/B/C): C | Applicability (1/2/3): 1

Outcome(s): | Results (Text)
Total thiamine | Levels of total thiamine were normal in all three brain areas, a non significant trend towards reduction predominantly in the temporal and occipital cortices

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Temporal cortex | Thiamine | pmol/mg of protein | p | Temporal cortex | Total thiamine | pmol/mg of protein | p
| | Mean | SE | % of change | | Mean | SE | % of change
AD | 20 | 9.0 | 0.7 | -1 | NS | 27.2 | 1.4 | -11 | NS
Controls | 18 | 9.0 | 0.7 | | NS | 30.7 | 1.3 | | NS

Description of (Sub-) Groups | N | Parietal cortex | Thiamine | pmol/mg of protein | p | Parietal cortex | Total thiamine | pmol/mg of protein | p
| | Mean | SE | % of change | | Mean | SE | % of change
AD | 20 | 9.9 | 0.8 | +9 | NS | 29.5 | 1.4 | -5 | NS
Controls | 18 | 9.1 | 0.6 | | NS | 31.1 | 1.3 | | NS

Description of (Sub-) Groups | N | Occipital cortex | Thiamine | pmol/mg of protein | p | Occipital cortex | Total thiamine | pmol/mg of protein | p
| | Mean | SE | % of change | | Mean | SE | % of change
AD | 20 | 10.1 | 0.8 | -8 | NS | 27.9 | 1.4 | -12 | NS
Controls | 18 | 11.0 | 0.7 | | NS | 31.6 | 1.3 | | NS

Total thiamine=thiamine monophosphate+thiamine+thiamine diphophate

Correlation

Author, Year: Maxwell, 2002 | Ref ID: 2072 | Vitamins: Folate
Objective: Association of folate level with future dementia

Study characteristics | | Population | | | Inclusion criteria | Exclusion criteria | Definitions
Study design | Longitudinal | Age: | 80.1 | SD 7.3 | Cases: | Cases: | AD: | nd (?DSM-III-R)
| Non-comparative | %Male: | 45% | | Canadian Study of Health and Aging (CSHA). Representative sample of Canadians aged 65 years and older. 18 centers in 5 regions across Canada. Both community and residents of institutions. All subjects scoring <78 on Modified Mini-Mental State (3MS) examination, random sample of those scoring ≥78, subjects unable to be screened, all institutionalized subjects invited for comprehensive clinical examination. No clinical dementia (at baseline) per DSM-III-R. Available folate data Re-contacted after 5 years.
| Prospective | Race: | nd | | | | PD:
Country: | Canada | Other: | | | | | VascDz:
Setting: | Community and Institutions | | | | | | Cognitively impaired but not dementia; Dementia: | DSM-III-R
Funding: Government; Pharmaceutical
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total
Folate quartile (by study center)* | Q1: <5–12 nmol/L | Modified Mini-Mental State (3MS), Baseline | 0–100 | N met inclusion criteria: | 523
| Q4: >14–36 nmol/L | Cognitive decline | Δ 3MS ≥10 | N analyzed: | 226–266
| | Dementia | DSM-III-R | Not analyzed (%): | ~50%
| | AD | ?DSM-III-R
Comments:

* ND on measurement method or normal range.

Other predictors/outcomes reported: | Adverse cerebrovascular event (primary outcome), death, institutionalized
Follow-up duration (if applicable): | 5 years
Reasons for drop out (if applicable): | Newfoundland (legal restrictions) 33; missing clinical data 47; no data 177–217
Limitations: | High proportion of unanalyzed subjects, without explanation
Quality (A/B/C): B | Applicability (1/2/3): 2

Correlation of Predictors with Outcomes

Outcome | N | All | | N | Q1 Folate | <5–12 nmol/L | N | Q2 Folate | (nd) | N | Q3 Folate | (nd) | N | Q4 Folate | >14–36 nmol/L | Q1 v Q4
| | Mean | SD | | Mean | SD | | Mean | SD | | Mean | SD | | Mean | SD
Baseline 3MS Score | 369 | 74.8 | 15.8 | 80 | 66.6 | 19.2 | | | | | | | 100 | 77.8 | 11.4 | P≤0.0001
3MS Decline (5 yr) | 266 | N=87 | | nd | 43.5% | | nd | 32.4% | | nd | 29.3% | | nd | 29.7% | | OR 2.16 (0.96, 4.86)
Dementia (incident) | 243 | N=66 | | nd | 38.1% | | nd | 27.3% | | nd | 23.1% | | nd | 24.3% | | OR 2.19 (0.93, 5.15)
AD (incident) | 226 | N=49 | | nd | 33.3% | | nd | 21.3% | | nd | 15.3% | | nd | 20.9% | | OR 2.17 (0.85, 5.53)

* Odds Ratio (95% confidence interval), adjusted for age and sex.

Correlation

Author, Year: McCaddon, 2004 | Ref ID: 2088 | Vitamins: B12
Objective: Association of B12 and transcobalamin polymorphism with AD (Clinical study)

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 79 (75–84) | 79 (73–84) | Cases: | Cases: | AD: | DSM-IV
| Comparative | %Male: | 30% | 38% | Features compatible with DSM-IV criteria for primary degenerative dementia of Alzheimer type | Receiving B12 supplementation (for B12 correlation)
| Prospective | Race: | nd | | | | PD:
Country: | UK | Other: | | | Controls: | Controls: | VascDz:
Setting: | Dementia clinic, outpatient | | | | Healthy, cognitively intact, age and sex matched elderly volunteers from a General Practice in a comparable SES area. | | Other:
Funding: Government
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | AD | Control
B12, serum* | ng/L | AD diagnosis | | N enrolled: | 144 | 70 | 74
Holo-transcobalamin** | pmol/L | | | N analyzed: | 136 | 65 | 71
Transcobalmin isotype | TC 776C>G | | | Drop-outs (%): | 6% | 7% | 4%
Comments:

* Bayer ACS:180 SE, chemiluminescence. ND on normal mean or range.

** Axis-Shield, solid-phase capture assay. ND on normal mean or range.

Other predictors/outcomes reported: | Holo-TC levels (the ability of transcobalamin to bind to cobalamin)
Follow-up duration (if applicable):
Reasons for drop out (if applicable): | nd
Limitations: | Numbers of subjects analyzed for B12 unclear. Unclear why dropouts. Combination of clinical and histopathology (with large * unanalyzed of autopsy cases) problematic
Quality (A/B/C): C | Applicability (1/2/3): 3

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Sr | B12 ng/L | p | Sr | Holo-TC ng/L | p | N | 776CC | 776CG | 776GG | p | 776C | 776G | p
| | Mean | range | | Mean | range | | | % | % | % | | Allele Frequency
AD | 47* | 333 | 272–420 | | 43 | (30–62) | | 65 | 25% | 52% | 23% | | 0.51 | 0.49
Healthy control | 74 | 342 | 296–455 | | 52 | (33–77) | | 71 | 37% | 51% | 12% | | 0.62 | 0.38
difference: | | | | 0.23 | | | 0.18 | | | | | NS** | | | 0.15**

* 23 subjects receiving B12 supplementation were excluded. Unclear if all had AD, but we assume this to be the case.

** The distribution is in Hardy-Weinberg equilibrium. There is a non-significant increase in TC776G allele frequency in the clinically diagnosed AD group.

Survival Curve Evaluation of Combined Clinical and Histopathology Studies

Outcome(s): | Results (Text)
Age of disease onset | N (AD)=74 clinical (living) + 35 histopathology cases (autopsy)
| N (Control)=70 clinical + 107 histopathology
| AD-free survival significantly greater for 776CC than either 776GG (P=0.008) or 776CG (P=0.02).
| Proportionately fewer people with 776CC appeared to develop AD at any given age.

Correlation

Author, Year: McCaddon, 2004 | Ref ID: 2088 | Vitamins: B12
Objective: Association of B12 and transcobalamin polymorphism with AD (Histopathology study)

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Median Age (at death): | 80 (75–85) | 78 (70–83) | Cases: | Cases: | AD: | CERAD criteria
| Comparative | %Male: | 38% | 53% | Histopathologically confirmed AD post-mortem (CERAD criteria)
| Retrospective | Race: | nd | nd | | | PD:
Country: | Sweden | Other: | | | Controls: | Controls: | VascDz:
Setting: | Autopsy (Brain bank) | | | | Died from cardiac disease or malignancy. No history of dementia or neuropsychiatric diseases | Macroscopic infarcts, AD | Other:
Funding: Government
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | AD | Control
Transcobalmin isotype | TC 776C>G | AD diagnosis | | N enrolled: | 201 | 94 | 107
| | | | N analyzed: | 201 | 94 | 107
| | | | Drop-outs (%):
Comments:

Other predictors/outcomes reported: | ApoE genotype
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Autopsy study with matched controls from brain bank; unadjusted
Quality (A/B/C): C | Applicability (1/2/3): 1

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of Sub-) Groups | N | 776CC | 776CG | 776GG | p | 776C | 776G | p
| | % | % | % | | Allele Frequency
AD | 94 | 34% | 48% | 18% | | 0.58 | 0.42
Non-AD control | 107 | 39% | 47% | 14% | | 0.63 | 0.37
difference: | | | | | NS | | | NS

See McCaddon 2004 RefID 2088 for combined study survival curve.

Correlation

Author, Year: Miller, 2002 | Ref ID: 2167 | Vitamins: B12, folate, B6
Objective: To investigate plasma Hcy, B6 status and the occurrence of vascular disease in patients with AD

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Case-control | Age: | 79 ±7 | 75 ± 6 | Cases: | Cases: | AD: | According to NINCDS/ARDRA criteria (REF 11)
| Comparative | %Male: | 35 | 46 | Subjects with Dx of possible or probable AD | ND
| Retrospective | Race: | ND | ND | | | PD:
Country: | US | Other: | | | Controls: | Controls: | VascDz:
Setting: | | | | | Volunteers of similar age without Dx of AD or other major neurodegenerative disease | ND | Other: | Hx stroke, MI, angina, CHF, CAD, TIA or presence of cerebral infarction documented on CT or MRI
Funding: Government | | | | | | | Coexisting vascular disease (VD):
Comments:

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
Plasma PLP | AD | NINCDS/ARDRA criteria | N enrolled: | 80 | 43 | 37
| | | N analyzed: | 80 | 43 | 37
| | | Drop-outs (%): | ND | ND | ND
Comments: Serum PLP was determined by radioenzymatic assay (ALPCO, Windham, NH); considered as low when value <25nmol/L

Other predictors/outcomes reported: | Age, gender, RBC folate, plasma B12, serum CRE, serum TSH, medication use (Aricept or B vit supplements)
Follow-up duration (if applicable): | N/A
Reasons for drop out (if applicable):
Limitations: | Statistically significant difference for age between cases and controls; unclear whether controls recruited from the same community as cases; power calculation not reported
Quality (A/B/C): B | Applicability (1/2/3): 2

Outcome(s): | Results (Text)
Low PLP (<25nmol/L) | The OR for low plasma PLP was 12.3 for patients with AD compared with subjects without AD. VD was not significantly associated with low PLP, nor did VD significantly modify the odds among those subjects with AD.

Correlation of Predictors with Outcomes (case control studies); Odds ratios for low PLP (<25nmol/L) in patients with AD and control subjects

Description of (Sub-) Groups | N | OR (Adj 1*)
AD | 43 | 12.3 | 1.8–84 | p=0.01
AD with VD (vs. AD without VD, n=32) | 11 | 3 | 0.46–19 | p=0.25
VD (AD, n=11 and normal, n=15) | 26 | 0.55 | 0.12–2.5 | p=0.43

* Adj 1, adjusted for age, gender, RBC folate, plasma B12, serum CRE, serum TSH, plasma Hcy

Correlation

Author, Year: Miller, 2003 | Ref ID: 2170 | Vitamins: Homocysteine, B-vitamin
Objective: To investigate the effect of L-DOPA and B-vitamin status on plasma homocysteine in PD pts

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 64 | 60 | Cases: > 30 yr, | Cases: | AD:
| Comparative | %Male: | 65% | 50% | | Pregnancy; OCP; other neurodegenerative diseases; malnutrition, depression or psychotic illnesses, other major medical disorders
| Prospective | Race: | | | | | PD: | Two out of three: rigidity, resting tremor and bradykinesia
Country: | US | Other: | | | Controls: | Controls: | VascDz:
Setting: | University outpatient clinic | | | | | | Other:
Funding: US government grants
Comments: Self-reported use of folate, B-12 or B-6 was similar between groups; more pts in treatment group on MAO B inhibitor or a dopamine receptor agonist than in the control group

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
L-DOPA treated PD pts | homocysteine | | N enrolled: | 40 | 20 | 20
Controls: PD pts not treated with L-DOPA | folate | | N analyzed: | 40
| B-12 | | Drop-outs (%):
| Pyridoxal-5′-phosphate (PLP)
Comments:

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 2

Outcome(s): | Results (Text)
| Plasma homocysteine was higher in treatment group than control (p=0.018).
| Plasma PLP was lower in treatment group than control (p=0.008).
| L-DOPA treated group: homocysteine vs. folate, R^2^ =0.487, p<0.001; homocysteine vs. vitamin B12, R^2^ =0.498, p<0.001; homocysteine vs. PLP, R^2^ =0.342, p=0.007. No correlation in the control group.

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | | plasma | folate | nmol/L | p | plasma | B-12 | pmol/L | plasma | PLP | nmol/L | p
| | | Mean | SD | r= | | Mean | SD | r= | Mean | SD | r=
L-DOPA treated | 20 | | 12.8 | 11.6 | | | 375 | 167 | | 78 | 99.1 | | 0.008
No L-DOPA | 20 | | 12.6 | 10.8 | | | 464 | 249 | | 154 | 150

Correlation

Author, Year: Mizrahi, 2004 | Ref ID: 2189 | Vitamins: B12, Folate
Objective: B12, Folate, Hcy in AD and healthy

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Year of birth: | 1915*+/-7.0 | 1927*+/-7.0 | Cases: | Cases: | AD: | DSM-IV
| Comparative | %Male: | 39% | 48% | AD, Arab villagers,
| Prospective | Race: | Arab | Arab | | | PD
Country: | Israel | Other: | | | Controls: | Controls: | VascDz:
Setting: | Rural | | | | Healthy, Arab villagers, | Memory complaints, indications of any inflammatory disorder | Other:
Funding:
Comments: This region has a high prevalence of AD despite low ApoE ε 4 allele frequency

* P<0.001 between groups

Predictor(s): (eg, B vit level) | | Outcome(s): | | Total | Population of interest | Control
Plasma B12* | pmol/L | AD Dx | N enrolled: | 235 | 79 | 156
Plasma Folate** | nmol/L | | N analyzed: | 230 | 75 | 155
(Plasma Hcy | μmol/L) | | Drop-outs (%): | 2% | 5% | 1%
Comments:

* ICN Pharmaceuticals, radioisotope dilution assay. B12 deficiency defined as <125 pmol/L.

** ICN Pharmaceuticals, radioisotope dilution assay. Folate deficiency defined as <3.6 nmol/L.

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable): | 2 Outlier Hcy (>54 μmol/L), 2 Outlier B12 (>850 pmol/L), 1 Hcy not available
Limitations:
Quality (A/B/C): A | Applicability (1/2/3): 3

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Plasma | Folate | nmol/L | p | Plasma | B12 | pmol/L | p
| | Mean | SD | r= | | Mean | SD | r=
AD | 75 | 4.3 | (3.2) | | NS | 322.9 | (136.0) | | NS
Healthy | 155 | 4.8 | (2.6) | | | 350.5 | (175.3)

Description of (Sub-) Groups | N | (Outcome)
| | OR (Adj 1*)
Plasma B12 >259.95 pmol/L | | 1
Plasma B12 203.70–259.95 pmol/L | 230 | 0.7 | (0.3–1.9)
Plasma B12 <203.70 pmol/L | | 1.3 | (0.5–3.4)
Plasma Folate >11.40 nmol/L | | 1
Plasma Folate 7.87–11.40 nmol/L | 230 | 1.3 | (0.5–3.7)
Plasma Folate <7.87 nmol/L | | 1.6 | (0.6–4.2)

* Adj 1, adjusted for year of birth and gender

Correlation

Author, Year: Molina, 2002 | Ref ID: 2196 | Vitamins: B1
Objective: To assess the lumbar CSF levels of thiamine and their phosphate esters in patients with sporadic AD compared with a control population and to relate the decreased levels with increased risk of AD

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS and Longitudinal | Age: | 72.6 (8.8) | 70.2 (7.6) | Cases: | Cases: | AD: | By DSM-IV; probable AD according to NINCDS-ADRDA; MMSE<23; Hachinski ischemic score <4 points; Hamiltonapos;s depression scale <17 points
| Comparative | %Male: | 46% | 44% | Unselected patients recruited during their first visit to neurology clinic in 2 hospitals in Madrid and fulfilling diagnostic criteria of AD | Therapy with vit supplements in the past 6 mo; ethanol intake >80g/d in past 6 mo; previous h/o chronic illnesses; atypical dietary habits; undernutrition; and previous h/o severe systemic disease
| Prospective and retrospective analysis for progression | Race: | ND | ND | | | PD:
Country: | Spain | Other: BMI | 24.4 (4.7) | 28.2 (3.4) | Controls: | Controls: Same as above | VascDz:
Setting: | Academic hospital | | | | Healthy non-demented and those with normal CSF finding | | Other:
Funding: Private non industry
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Plasma thiamine | Nmol/L | MMSE | <23 for AD | N enrolled: | 65 | 33 | 32
CSF thiamine | Nmol/L | | | N analyzed: | 65 | 33 | 32
| | | | Drop-outs (%): | 0
Comments: Plasma and CSF thiamine was analyzed by ion pair reversed phase high performance liquid chromatography; normal reference level ND

Other predictors/outcomes reported:
Follow-up duration (if applicable): | Unclear; per yr progression for AD available
Reasons for drop out (if applicable): | NA
Limitations: | Unclear how per yr progression was assessed for 20 patients
Quality (A/B/C): C | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
MMSE | Significant correlation between MMSE and plasma thiamine diphosphate r=0.41, p<0.05 Free thiamine correlated significantly with MMSE in both AD patients r=0.84; p<0.01 and controls r=0.40, p<0.05

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | CSF | TDP | nmol/L | p | CSF | TMP | nmol/L | p | CSF | Free thiamine | nmol/L | p | CSF | Total thiamine | nmol/L | p
| | Mean | SD | r= | | Mean | SD | r= | | Mean | SD | r= | | Mean | SD | r=
AD | 33 | 2.55 | 1.70 | | NS | 3.57 | 3.84 | | NS | 1.17 | 3.03 | | NS | 7.29 | 6.98 | | NS
Controls | 32 | 3.21 | 2.28 | | | 4.30 | 2.40 | | | 2.20 | 3.20 | | | 9.46 | 4.52

Description of (Sub-) Groups | N | Sr | TDP | nmol/L | p | Sr | TMP | nmol/L | p | Sr | Free thiamine | nmol/L | p | Sr | Total thiamine | nmol/L | p
| | Mean | SD | r= | | Mean | SD | r= | | Mean | SD | r= | | Mean | SD | r=
AD | 33 | 2.22 | 1.74 | | <.05 | 1.32 | 2.02 | | NS | 1.16 | 1.21 | | <.05 | 4.75 | 7.72 | | <.05
Controls | 32 | 3.23 | 1.87 | | | 2.20 | 3.20 | | | 2.61 | 2.93 | | | 7.88 | 5.79

Correlation

Author, Year: Morris, 2001 | Ref ID: 2229 | Vitamins: folate
Objective: To evaluate the relation between serum tHcy and performance on short delayed-recall tests of elderly men and women

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 70.1±0.5yr | | Cases: | Cases: | AD:
| Comparative | %Male: | 42 | | Men and women aged ≥ 60yr who participated in phase III NHANES (1991-94); available tHcy measured levels | < 8 yr follow-up; Hx of stroke; unable to learn the word: “apple, table, and penny” in one try; subjects who had asked for the tests to be administered in a language different from that reportedly spoken at home
| Retrospective | Race: | 89.2% non-Hispanic white | | | | PD:
Country: | US | Other: | 53.7% had smoke previously; 11.8% had been heavy alcohol users at one time; 36% had taken vitamins, minerals within 24h of the interview, 12.6% had high BP, 38.1% had a household income<US$ 20,000/yr | | Controls: | Controls: | VascDz:
Setting: | community | Education years, mean | 12.3 ±0.2 | | | | Other:
Funding: ND
Comments: Characteristics are given for total population not separately for the comparative groups

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
RBC folate, serum folate | “Apple, table, penny” test | Dichotomous outcome 0, >0 | N enrolled: | 1270 | ND | ND
| | | N analyzed: | 1145 | 37 | 1108
| | | Drop-outs (%): | 125 | ND | ND
Comments: RBC folate and serum folate was measured according to standardized protocol

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
RBC folate, serum folate | Patients in the upper half of the serum folate distribution; patients in the lower half of the serum folate distribution | Paragraph delayed recall test | Continuous scale 0–6 | N enrolled: | 1200 | ND | ND
| | | | N analyzed: | 1141 | ND | ND
| | | | Drop-outs (%): | 59
Comments:

Other predictors/outcomes reported: | tHcy, sex; age; years of education; race-ethnicity; pack-years of cigarette smoking; heavy alcohol use; high BP; BP medication use; blood lead concentration; selenium; TCHOL; triacylglycerol; CRE; Fe; total Calcium; β-carotene; Vit A, B12, C, E; householdincome
Follow-up duration (if applicable): | N/A
Reasons for drop out (if applicable): | Demographic data not available
Limitations: | Unkown whether the population included patients with dementia, etc or not; exact results (β coefficient, etc) not given; inconsistencies between text and table legend (Hcy correlation with serum folate)
Quality (A/B/C): C | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
“Apple, table, penny” test | Part of the MMSE (REF 14); the subjects' score on the test is a number from 0 to 3, corresponding to the number of the 3 items successfully recalled after the delay
Paragraph delayed recall test | The test was administered by trained lay interviewers according to a standard protocol (REF 11). All subjects were told that a short story would be read to them, subsequent to which they would be asked to repeat the story back to the interviewer. Then, the interviewer continued with a few additional questions unrelated to the story or to cognitive function. Finally, the subjects were asked to repeat the story a second time. The was scored according to the 6 main story ideas recalled by the subjects after the brief delay. This test is characteristic of a type of test commonly used to evaluate short-term verbal memory (REF 15). Also such tests may be particularly effective at distinguishing between subjects who will and will not progress to a Dx of AD
Paragraph delayed recall test | Patients in the upper half of the serum folate distribution recalled on average >4 of the 6 main ideas of the story; patients in the lower half of the serum folate distribution recalled significantly fewer stories (p<0.001)

Correlation of Predictors with Outcomes (cross-sectional studies); Folate levels in different groups according to paragraph delayed recall test score

Description of (Sub-) Groups | N | Sr | folate | nmol/L | p | RBC | folate | nmol/L | p | (Sr/CSF) | (B vit) | (unit) | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | SE/SD | r= | | Mean | SE/SD | r= | | Mean | SE/SD | r= | Mean | SE/SD | r=
Paragraph delayed recall test 0 | 37 | 12.3 | ND | ND | | 464 | ND | ND
Paragraph delayed recall test 1 | 27 | 13.5 | ND | ND | | 399 | ND | ND
Paragraph delayed recall test 2 | 82 | 16.8 | ND | ND | | 433 | ND | ND
Paragraph delayed recall test 3 | 200 | 18 | ND | ND | | 545 | ND | ND
Paragraph delayed recall test 4 | 333 | 17.6 | ND | ND | | 488 | ND | ND
Paragraph delayed recall test 5 | 306 | 18.9 | ND | ND | | 534 | ND | ND
Paragraph delayed recall test 6 | 158 | 18.4 | ND | ND | | 545 | ND | ND

Significant relation with recall score and tHcy levels after adjusted for age, sex, race-ethnicity, years of education, and income (p<0.05); linear regression model

Folate levels in different groups according to “Apple, table, penny” test score

Description of (Sub-) Groups | N | Sr | folate | nmol/L | p | RBC | folate | nmol/L | p | (Sr/CSF) | (B vit) | (unit) | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | SE/SD | r= | | Mean | SE/SD | r= | | Mean | SE/SD | r= | Mean | SE/SD | r=
“Apple, table, penny” test 0 | 37 | 14.2 | ND | ND | | 455 | ND | ND
“Apple, table, penny” test >0 | 1108 | 17.8 | ND | ND | | 513 | ND | ND

Serum folate concentration interacted significantly with the serum tHcy concentration in relation to story recall but not to word recall

Correlation

Author, Year: Nagga, 2003 | Ref ID: 2275 | Vitamins: Folate
Objective:

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Studydesign | XS | Age: | | 69 | Cases: | | AD: ICD-10 criteria
| | AD* | 75 | | Consecutive patients evaluated for dementia from January 1995 - December 1997, | Cases: Current cobalamin and/or folate substitution, subgroup N < 3
| | AD w/CVD* | 76
| | VD* | 78
| | Cognitive impaired | 75
| Comparative | %Male: | 37 | 51
| Prospective | Race: | ND | | | | PD:
Country: | Sweden | Other: | | | Controls: | Controls: | VascDz:
Setting: | In/out-patient geriatric clinic of university hospital | | | | ≥ 60 yr, randomly selected from general population screened for gastritis with gastroscopy, biopsy, & blood samples in fasting state, no MMSE data | | Other:
Funding: Public & private
Comments: *Statistical lower age for controls vs population, except mild cognitive impaired subgroup; differential diagnoses by ICD-10 criteria; none treated for dementia at enrollment; no MMSE data for control group

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Serum folate | nmol/l | Dementia | ICD-10 | N enrolled: | 224 | 64 (59 VD) | 101
| | | | N analyzed: | 224
| | | | Drop-outs (%): | NA
Comments:

Fluoroimmunoassay - reference range 75–475 nmol/l

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: Analyses for nonfasting patient group vs fasting control group
Quality (A/B/C): C | Applicability (1/2/3): 3

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Sr | Folate | (unit) | p
| | Mean | SD | r=
AD | 47 | 191 | 75
AD w/CVD | 9 | 165 | 89
Cognitively impaired | 8 | 279 | 115 | | <.05
Control | 101 | ND | ND

AD & AD w/CVD had lower levels of blood folate vs cognitively impaired

Correlation

Author, Year: Nilsson, 1996 | Ref ID: 2337 | Vitamins: B 12, folate
Objective: To determine plasma tHcy and its main determinants sr cobalamin, blood folate, and sr creatinine in dementia patients and in reference population

Study characteristics | | Population (DAT) | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 75±10 | 75±7 | Cases: | Cases: | AD: | ND; diagnosed clinically, psychometric tests, rCBF, EEG, CT and MRI in extreme dementia
| Comparative | %Male: | ND | 52 | Elderly patients with suspected dementia or other organic brain diseases and referred to the psychogeriatric dept in good nutritional status | Ongoing or those with recently discontinued vit supplementation, or with creatinine >120 μmol L^-1^, patients on extreme diets
| Prospective | Race: | Probably white | | | | PD: | Unclear
Country: | Sweden | Other: | | | Controls: | Controls: | VascDz: | Same as AD
Setting: | Academic hospital | | | | Local population invited for participation in the study | Unwilling or unable to participate, younger than 60 yr, or sr creatinine >120 μmol L^-1^ | Other: | Frontotemporal dementia and other dementia includes alcohol and braintumor
Funding: University and private non-industry
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Sr cobalamin* | 110–650 pmol/L | DAT | ND | N enrolled: | 295 | 68 | 163
Blood folate** | 125–500 nmol/L | | | N analyzed: | 295 | 68 | 163
| | | | Drop-outs (%): | 0%
Comments: Radioassay using vit B12/folate Dual RIA kit

Other predictors/outcomes reported: | THcy; sr creatinine
Follow-up duration (if applicable): | NA
Reasons for drop out (if applicable): | NA
Limitations: | Xs study; all dementia included for correlational analysis; only levels of B12/folate available for DAT. Unclear definition for DAT not specified
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text)
All dementia | Significant correlations between the levels of vitamin folate and B12, plasma tHcy in both demented and non demented patients in both groups taken together. No data available for DAT alone

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Sr | B 12 | pmol/L | p | Sr | folate | nmol/L | p | (Sr/CSF) | (B vit) | (unit) | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | SD | r= | | Mean | SD | r= | | Mean | SE/SD | r= | Mean | SE/SD | r=
DAT | 68 | 245 | 98 | ND | | 294 | 132 | ND | <0.05
Controls | 163 | 256 | 120 | | | 353 | 156

Correlation

Author, Year: Nilsson, 2003 | Ref ID: 2343 | Vitamins: B12, folate
Objective: To evaluate the association of biochemical tests with morbidity, drug therapy, anthropometry, and gender

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS/Longitudinal | Age: | M: 84.4 range: 82–95 | | Cases: | Cases: | AD: | According to NINCDS/ARDRA
| | | F: 85.1 range: 82–100
| Comparative | %Male: | 38 | | Sample from population-based Swedish twin registry: all like-sex (monozygotic and dizygotic) twin pairs aged ≥ 80 with both members still alive during 1991-94 and agreed to give blood samples
| Prospective | Race: | | | | | PD:
Country: | Sweden | Other: | | | Controls: | Controls: | VascDz:
Setting: | community | | | | | | Other: | Dementia according to DSM-III-R criteria (F00-03)
Funding: Government (US)
Comments: Although study design is for longitudinal study, results for dementia are analyzed as XS (comparison of vit levels among different groups at a certain time-point)

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
B12 | Dementia | DSM-III-R criteria | N enrolled: | 535 | 86 | N/A
folate | Dementia | DSM-III-R criteria | N analyzed: | 535 | 86 | N/A
| | | Drop-outs (%): | N/A | N/A | N/A
Comments: Population (N: 535) also includes people with other morbidities not extracted for the purpose of this project; 256 subjects are reported as having intact cognition but it is not clear whether they are compared to demented sub-group); cases on B12-therapy were excluded; B12, folate: analyzed by time-resolved fluoroimmunoassay using an AutoDelfia instrument (Wallac); normal values for B12: 284 pmol/L and folate: 10.5 pmol/L

Other predictors/outcomes reported: | Albumin, calcium, TCHOL, HDL, -GT, potassium, sodium, urea, urate, CRE, free T4, TSH, homocysteine, BMI, waist circumference
Follow-up duration (if applicable): | N/A
Reasons for drop out (if applicable): | N/A
Limitations: | High number of comparisons may lead to significant results by chance; results at a significance level <0.001 should be interpreted with caution; results and discussion are mixed together with not much clarity
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text)
Dementia | Folate was significantly lower in women with dementia (p<0.005); NS differences for B12

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | (Sr) | (B 12) | (pmol/L) | p | (Sr) | (folate) | (pmol/L) | p | (Sr/CSF) | (B vit) | (unit) | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | SE/SD | r= | | Mean | SE/SD | r= | | Mean | SE/SD | r= | Mean | SE/SD | r=
Male with dementia (Dx before 1995) | 20 | 215 | | | | 9.3
Male with intact cognition | 83 | 313 | | | | 10.8
Female with dementia (Dx before 1995) | 66 | 257 | | | | 8.1 | | | <0.005
Female with intact cognition | 173 | 297 | | | | 10.5

Correlation

Author, Year: Postiglione, 2001 | Ref ID: 2583 | Vitamins: Folate, B12
Objective: Correlate B vitamins to AD and MTHFR gene

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Case-control | Age: | 68 | | Cases: | Cases: | AD: | DSM-IV, NINCDS-ADRDA
| Comparative | %Male: | 39% | | AD, living at home, able to eat unaided | Vascular dementia. Institutionalized or hospitalized in previous 3 mo. Vitamin supplementation, substances affecting homocysteine metabolism.
| Retrospective | Race: | nd | | | | PD:
Country: | Italy | Other: | | | Controls: | Controls: | VascDz: | NINDS-AIREN
Setting: | Memory clinic | | | | No dementia. MMSE>27. Mostly from among those who accompanied cases. | Disease affecting homocysteine metabolism. | Other:
Funding: nd
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Plasma folate* | ng/mL & nmol/L | AD diagnosis | | N enrolled: | | 74 | 74
Plasma B12** | pg/mL & pmol/L | | | N analyzed: | | 74 | 74
C677T MTHFR mutation*** | | | | Drop-outs (%):
Comments:

* IMX system (Abbott). Normal range 3.1–12.4 ng/mL

** IMX system (Abbott). Normal range 179–1132 pg/mL

*** PCR

Other predictors/outcomes reported: | Homocysteine
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 2

Outcome(s): | Results (Text)
Interaction of B12 or Folate and MTHFR | No significant differences in B12 or Folate levels by subcategories of cases or controls who were homozygous for MTHFR C677T or non-homozygous
Interaction of B12 and Folate with AD duration | Statistically significant correlation between duration of disease (months) and plasma folates (r = -0.580, P<0.05) and B12 (r = -0.460, P<0.05). Thus a decrease in B vitamin levels with AD duration.

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Plasma | B12 | pmol/L | p | Plasma | Folate | nmol/L | p | Plasma | B12 | pmol/L | p | Plasma | Folate | nmol/L | p
| | Mean | SD | UNADJ | | Mean | SD | UNADJ | | Mean | SD | ADJ* | | Mean | SD | ADJ*
AD | 74 | 491 | 144 | | <.001 | 5.7 | 2.1 | | <.001 | 689 | 301 | | NS | 8.9 | 3.3 | | NS
Healthy | 74 | 780 | 211 | | | 8.5 | 3.2 | | | 701 | 234 | | | 7.8 | 3.7
AD | 74 | 4/74 (5%) < 179 pg/mL | | | nd | 15/74 (20%) < 3.1 ng/mL | | | nd
Healthy | 74 | | 0% | | | | 0%

* Adjusted for age, serum creatinine, and duration of AD

Correlation

Author, Year: Quadri, 2004 | Ref ID: 2604 | Vitamins: Folate, vit B12
Objective: To examine the associations of plasma tHcy, sr folate, vit B12 concentration with mild cognitive impairment, AD, VascDz, and to inquire into the relationships between the biochemical variables and neuroradiologic mechanisms

Study characteristics | | Population: AD | | Cog impaired | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 79.1±7.7 | 76.1±7.1 | 75.6±8.5 | Cases: | Cases: | AD: | NINCDS-ADRDA and CERAD for probable or possible AD
| Non-Comparative | %Male: | 34.3 | 40.7 | 38.2 | consecutive subjects from the memory clinic with dementia and Cog impaired | Younger than 60 yr, with an isolated cognitive deficit, affected by dementias other than AD or VaD, or whose plasma tHcy conc not available, or those with vit B12 >600 pmol/L, folate >30 nmol/L or serum creatinine >180 μmol/L
| Prospective | Race: | Probably 100% W | Probably 100% W | Probably 100% W | | | PD: | NA
Country: | Switzerland | Other: Alcohol intake % >drinks/d | 0 | 1.2 | 1.8 | Controls: | Controls: | VascDz: | Based on CERAD criteria
Setting: | Hospital clinic | Education | 7.9 ±2.5 | 9.1 ±3.6 | 9.9 ±3.8 | elderly controls free of cognitive impairment | ND | Other: | Cognitively impaired 0.5 level on the clinical dementia rating scale
Funding: ND
Comments: NINCDS-ADRDA and CERAD: National Institute of Neurological and Communicative Disorders-Alzheimers Disease and Related Disorders Association and of the Consortium to Establish a Registry for Alzheimers disease for possible AD

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | | Control
Serum vit B12* | ND | MMSE | 0–30 | N enrolled: | 210 | AD=74 | Cog Impair=81 | 55
Serum folate** | ND | Minimum medial temporal thickness | mm | N analyzed: | 210 | 74 | 81 | 55
| | | | Drop-outs (%): | 0%
Comments:

125 B12 measured with a radioimmunoassay kit with the use of I and for folate with ^57^Co: normal range not specified

Other predictors/outcomes reported: | Plasma tHcy
Follow-up duration (if applicable): | NA
Reasons for drop out (if applicable): | —
Limitations: | Cross-sectional study; reference range for vitamins not available
Quality (A/B/C): B | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
CT appearance of white matter lesions | NS association with lower folate or vit B12 concentration in the demented group or in the whole sample

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Sr | folate | nmol/L | p | Sr | B12 | pmol/L | p | CT scan | Min medial temporal lobe thickness | mm | p
| | Mean | SD | r= | | Mean | SD | r= | | Mean | SD | r=
AD | 74 | 13.6 | 5.6 | | 0.04 | 281 | 111 | | NS | 12.2 | 2.6 | | NS
CDR 0.5 | 81 | 14.0 | 5.9 | | 0.04 | 275 | 117 | | NS | 13.7 | 3.0 | | NS
Control | 55 | 16.9 | 5.8 | | | 278 | 99 | | | 14.5 | 1.9

Description of (Sub-) Groups | N | Among CDR 0.5 | | | | N | AD patients
| | OR (Adj 1*) | | OR (Adj 2*) | | | OR (Adj 1*) | | OR (Adj 2*)
Vit B12 (Reference gp) >303 pmol/L | 81 | 1 | | 1 | | 74 | 1 | | 1
Vit B12 234–303 pmol/L | | 0.8 | (0.3, 2.0) | 0.8 | 0.3, 2.0 | | 0.6 | 0.2, 1.7 | 0.3 | 0.1, 1.1
Vit B12 <234 pmol/L | | 1.0 | (0.4, 2.4) | 0.7 | 0.3, 1.8 | | 0.8 | 0.3, 2.0 | 0.7 | 0.4, 1.2
Sr folate (Reference gp) >19.5 nmol/L | 81 | 1 | | 1 | | 74 | 1 | | 1
Sr folate 13.5–19.5 nmol/L | | 1 | 0.4, 2.8 | 0.9 | 0.3, 2.6 | | 2.1 | 0.7, 6.4 | 2.1 | 0.6, 6.8
Sr folate <13.5 nmol/L | | 3.4 | 1.3, 8.7 | 3.1 | 1.2, 8.1 | | 3.7 | 1.3, 10.7 | 3.5 | 1.1, 11.2

* Adj 1, adjusted for for age, gender, education and creatinine ...

Adj 2*) age, gender, education and creatinine, Hcy, vit B12 and folate

Correlation

Author, Year: Ravaglia, 2000 | Ref ID: 2642 | Vitamins: B12, folate, B6 (extracted)
Objective: To study the association between cognitive status and plasma tHcy levels in centenarians

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | ~100 | N/A | Cases: | Cases: | AD: | Clinical Dx (McKahn et al, 1984)
| Comparative | %Male: | 32 | N/A | Centenarian residents in 2 Provinces (Ravenna and Bologna), who underwent a standardized assessment for cognitive function, from Jan 1994 to Jan 1995 | Blood specimens not available
| Prospective | Race: | ND | N/A | | | PD: | ND
Country: | Italy | Other: | | | Controls: | Controls: | VascDz: | WHO, 1992
Setting: | community | | | | N/A | N/A | Other: | Cognitively impaired-not demented: (Dementia as defined by DSM IV criteria, APA 1994
Funding: government
Comments: 13 participants had no cognitive problem

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
B6 level | AD | | N enrolled: | 66 | 34 | N/A
B6 level | Cognitively impaired-not demented | | N analyzed: | ND | 10 | N/A
B6 level | Normal cognitive status | | Drop-outs (%): | N/A | 13 | N/A
Comments: B6 measured by HPLC (for pyridoxal-5′-phosphate: active coenzyme form of B6); lower reference value for plasma B6: 11.7 nmol/L

Other predictors/outcomes reported: serum Cre; serum folate; serum B12; plasma tHcy
Follow-up duration (if applicable): N/A
Reasons for drop out (if applicable): N/A
Limitations: power calculations not measured; results not reported
Quality (A/B/C): C | Applicability (1/2/3): 1

Outcome(s): | Results (Text)
B6 deficiency | B6 deficiency was present in 85% of normal centenarians, 50% of cognitively impaired not-demented, and 64.7% of AD. Among VascDz patients 40% had B6 deficiency; Among the 3 patients with other dementia (PD, alcoholism, and hypothyroidism) 1 had B6 deficiency
Cognitive status (AD, Cognitively impaired-not demented, Normal) | NS difference among the groups was found for B6 (ANOVA followed by multiple comparisons Tukey test, F:0.734, p=0.485)

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | (Sr) | (B 6) | (nmol/L) | p | (Sr/CSF) | (B vit) | (unit) | p | (Sr/CSF) | (B vit) | (unit) | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | SE/SD | r= | | Mean | SE/SD | r= | | Mean | SE/SD | r= | Mean | SE/SD | r=
AD | 34 | 9.8
Cognitively impaired-not demented | 10 | 11.9
Normal cognitive status | 13 | 8.1

B6 measured by HPLC (for pyridoxal-5′-phosphate: active coenzyme form of B6); lower reference value for plasma B6: 11.7 nmol/L

Correlation

Author, Year: Ravaglia, 2003 | Ref ID: 2644 | Vitamins: Folate, B12
Objective:

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | | NA | Cases: All residents of Conselice Municipality (Ravenna Province), ≥65yr, MMSE ≥ 24 | Cases: medical condition or drug tx affecting tHcy concentrations: hx AMI, stroke/transient ischemic attacks, liver disease, reduced renal excretion, cancer, vitamin tx, theophylline tx, psychotropic drugs, cytotoxic drugs, HRT; cognitive impairment: epilepsy, psychiatric illness, sensory-motor impairments affecting neuropsychological testing, clock drawing test score ≤ 6, one or more ADL | AD:
| | MMSE
| | 24–25 | 78.6
| | 26–28 | 73.1
| | >28 | 71.8
| Comparative | %Male: | 45 | NA
| Prospective | Race: | ND | NA | | | PD:
Country: | Italy | Other: | | | Controls: | Controls: | VascDz:
Setting: | Community | | | | | | Other:
Funding: Government
Comments: Subjects had clinical exam, MMSE, & interview for lifestyle, medication use, medical history, sociodemographic, dietary information.

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
Serum folate* | MMSE | 30 pt Italian version | N enrolled: | 650
Serum vitamin B12* | MMSE | 30 pt Italian version | N analyzed: | 650
| | | Drop-outs (%): | NA
Comments:

* Immunoelectrochemiluminescence analysis - Elecsys Folate Immunoassay & Elecsys B12 Immunoassay for Elecsys 2010 System; lower reference values 5.7 nmol/L for serum folate and 148 pmol/L vit B12

Other predictors/outcomes reported: | Predictor serum creatinine significantly higher in MMSE score 24–25 than score >28, Plasma tHcy significantly higher in group with MMSE 26–28 than MMSE > 28 & group MMSE 24–25 higher than MMSE 26–28; trend for increase physical activity to increase MMSE scores
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): C | Applicability (1/2/3): 2

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Sr | B 12 | (unit) | p | Sr | Folate | unit | p
| | Mean | 95%CI | r= | | Mean | 95% CI | r=
MMSE 24–25 | 46 | 233 | 206 – 264 | NA | | 11.4 | 10.0 – 13.0 | NA
MMSE 26–28 | 259 | 240 | 228 – 253 | | NS | 11.3 | 10.7 – 11.9 | | NS
MMSE >28 | 345 | 237 | 227 – 248 | | | 11.6 | 11.1 – 12.2

Correlation

Author, Year: Ravaglia, 2004 | Ref ID: 2646 | Vitamins: B12, folate, B6 (extracted)
Objective: To study the association between specific cognitive skills and plasma tHcy levels in healthy and cognitively normal elderly community dwellers and to analyze several potential confounders of tHcy levels

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Cohort | Age: | 72.9 +/-SD 8.2 Range 65–91yr | N/A | Cases: | Cases: | AD:
| Non-comparative | %Male: | 53 | N/A | All residents of Conselice Municipality (Ravenna Province), aged ≥65yr | Institutionalization; major sensory deficits; epilepsy; major psychiatric illness; infections of the brain; surgical intervebtion for brain tumor or aneurisms; mental retardation; significant developmental learning disorders; focal brain lesions; alcoholism; head trauma with loss of consciousness >1h; GDS ≥20; dementia; loss of dependence in IADL due to cognitive impairment; Hx acute MI, stroke or TIA; current liver disease; reduced renal excretion (Cre serum>133μmole/L); cancer; DM; Tx with Vit, theophylline, psychotropic drugs, cytotoxic drugs, and ERT
| Retrospective | Race: | ND | N/A | | | PD:
Country: | Italy | Other: | Education, yr: 4.3 +/-SD 1.5 | | Controls: | Controls: | VascDz:
Setting: | community | | | | N/A | N/A | Other: | Demetnia (used as exclusion criterion) defined by DSM IV, APA 1994
Funding: ND
Comments: Included participants were all non-demented healthy elderly people

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
B6 | Mental Deterioration Battery (MDB) | 7 parts that provide info for different areas of cognition: Reye's 15 word immediate and delayed recall for verbal memory, phonemic word fluency and sentence construction for language, Raven's progressive matrices '47 for logical reasoning, immediate visual memory for visual memory, freehand copying of drawings and landmarks for constructional praxis | N enrolled: | 62 | | N/A
| Prose memory test, IGNSA 1987 | | N analyzed: | ND | | N/A
| Corsi block tapping test, IGNSA 1987 | Evaluation of short-term spatial memory | Drop-outs (%): | N/A | | N/A
| MMSE | Italian version
Comments: B6 measured by HPLC (for pyridoxal-5′-phasphate: active coenzyme form of B6)

Other predictors/outcomes reported: | age; years of education; serum Cre; serum folate; serum B12; plasma tHcy
Follow-up duration (if applicable): | N/A
Reasons for drop out (if applicable): | N/A
Limitations: | non-controlled study; power calculations not measured; results not reported
Quality (A/B/C): C | Applicability (1/2/3): 1 (healthy elderly who live in a small community in Italy)

Outcome(s): | Results (Text)
Neuropsycologiacal measures | NS association between B6 levels and neuropsycologiacal measures (specific results not given)

Correlation

Author, Year: Refsum, 2003 | Ref ID: 2661 | Vitamins: B12
Objective: Evaluation of holotranscobalamin in cognitively impaired

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 75.2 (72.8–77.7) | 70.5 (68.4–72.7) | Cases: | Cases: | AD: | CERAD criteria
| Comparative | %Male: | 43% | 32% | Varying degrees of cognitive dysfunction, referred to Oxford Project to Investigate Memory and Ageing. Histologically confirmed at autopsy. Serum available for re-testing | Age <55 y, no blood sample available (original criteria)
| Retrospective | Race: | nd | nd | | | PD:
Country: | UK | CAMCOG: | 39.3 (33.9–44.8) | 100.4 (95.6–105.2) | Controls: | Controls: | VascDz:
Setting: | Clinic | MMSE | 11.4 (9.8–13.0) | 28.9 (27.5–30.3) | Elderly volunteer controls without symptoms of memory impairment (some of whom were patients' relatives). Serum available for re-testing | | Other:
Funding: Pharmaceutical
Comments: SUBSET OF CLARKE 1998 REF ID 622. Later re-evaluation of same subjects.

CAMCOG, Cambridge Cognitive Examination, maximum score 107

MMSE, Mini-Mental Status Examination, maximum score 30

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Holotranscobalamin (holoTC)* | pmol/L | AD diagnosis | | N enrolled: | 116 | 51 | 65
metabolically active fraction of plasma cobalamins | | | | N analyzed: | 116 | 51 | 65
| | | | Drop-outs (%):
Comments:

* Axis-Shield, solid phase RIA. Normal range determined as part of study.

Other predictors/outcomes reported: | Serum cobalamin (total), (Serum folate: see Clarke 622)
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text)

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Serum | HoloTC | (pmol/L) | p
| | Geometric Mean | Range | r=
AD (histology) | 51 | 41.1 | (36.1–46.8) | | <0.001
Controls | 65 | 57.1 | (51.1–64.1)
ALL | | OR (Adj 1*) | | OR (Adj 2*)
Low holoTC (<40 pmol/L) | 116 | 3.40 | (1.45–7.97) | 2.82 | (1.02–7.83)
HIGH Hcy (>14 μmol/L)
Low holoTC (<40 pmol/L) | ~58 | 9.45 | (2.31–38.7)
LOW Hcy (<14 μmol/L)
Low holoTC (<40 pmol/L) | ~58 | 0.91 | (0.15–5.31)

* Adj 1, adjusted for age and sex, and total cobalamin, MMA, Hcy, and Folate; Adj 2, adjusted for age, sex, smoking, social class, and ApoE ε4, and total cobalamin, MMA, Hcy, and Folate.

Correlation

Author, Year: Regland, 1988 | Ref ID: 2663 | Vitamins: B12, folate
Objective:

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | | 72 | Cases: | Cases: ND | AD: DSM-III
| | AD | 59
| | Senile dementia | 75
| Comparative | %Male: | ND | ND | Hospital geropsychiatric unit dementia patients
| Retrospective | Race: | ND | ND | | | PD:
Country: | Sweden | Other: | | | Controls: | Controls: | VascDz:
Setting: | Inpatient geropsychiatric unit | | | | Hospital geropsychiatric unit dementia patients diagnosed with vascular dementia | | Other:
Funding: Government grant & private foundations
Comments: 66 yr cut-point for AD vs senile dementia of AD type

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Serum B12 | pmol/l | Dementia | DSM-III criteria | N enrolled: | 145 | 91 | 54
Blood folate | nmol/l | | | N analyzed: | 145 | 91 | 54
Plasma folate | nmol/l | | | Drop-outs (%):
Comments: Medication and nutrition history unavailable for analyses

Isotope dilution assay

Reference limit for blood folate 90–450 nmol/l

Other predictors/outcomes reported: Stratification of total group by serum B12 levels at 200 pmol/l resulted in patients with low B12 were older and blood folate was lower than normal B12 level; negative correlation between serum B12 levels and platelet MAO activity (r = -0.33, p < 0.002), negative correlation for HVA and vitamin B12 (r = -0.23, p < 0.02)
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 1

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Serum | B12 | (unit) | p | Plasma | Folate | (unit) | p | Blood | Folate | (unit) | p
| | Mean | SD | r= | | Mean | SD | r= | | Mean | SD | r=
Control | 54 | 335 | 184 | | | 13 | 8 | | | 277 | 144
AD | 35 | 319 | 132 | | 0.0002 | 11 | 4 | | NS | 262 | 77 | | NS
Senile dementia | 56 | 246 | 158 | | | 12 | 5 | | | 244 | 84

Serum vitamin B12: Control > Senile dementia, AD > Senile dementia

Mean vitamin B12 concentrations levels for control & AD groups were normal vs low concentration for senile dementia group

Correlation

Author, Year: Religa, 2003 | Ref ID: 2678 | Vitamins: B12, folate
Objective: To examine the relationship between plasma Hcy levels and vit status and to identify the genetic status of the ApoE and MTHFR gene polymorphism in Polish AD, mild cognitive impairment and age matched controls

Study characteristics | | Population AD | | MCI | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 74.2(6.3) | 70.7(7.0) | 71.2 (6) | Cases: | Cases: | AD: | Meeting the criteria of NINCDS_ADRDA fro probable AD and also DSM-IV
| Comparative | %Male: | ND | ND | ND | AD patients from the Alzheimer day clinic by examination clinical and radiological
| Prospective | Race: | ND | ND | ND | | | PD:
Country: | Poland | Other: | | | | Controls: | Controls: | VascDz:
Setting: | Academic medical | | | | | MCI patients from the clinic and examined by a panel of specialists and neurologists | Cognitively intact patients from surgical and medical wards or spouses of AD patients | Other:
Funding: Gov and Foreign grants | | | | | | | | Mildly cognitive impaired | Clinical dementia rating scores of 0.5 and global deterioration scale scores of 3 and presented with memory complaints but not severe enough to fit in dementia criteria
Comments: Cognitively intact healthy adults based on MMSE score MMSE: 29(+/-1) normal

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Folic acid | 5.3–14.4 ng/ml | Classification of study population based on clinical dementia rating score and other clinical symptoms and MMSE | MMSE: 29(+/-1) normal | N enrolled: | 297 | 99 | 98 MCI+100 healthy
Vit B12 | 157–1059 pg/mL | | | Nanalyzed: | 297 | 99 | 198
| | | | Drop-outs(%): | na
Comments: Folate by AxSYM folate reagent assay and vit B12 by immunoassay; Normal ranges in the table

Other predictors/outcomes reported: | MTHFR gene polymorphism; ApoE; homocysteine
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | No adjustment of cross-sectional data
Quality (A/B/C): C | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
tHcy | The mean plasma tHCy levels were sig higher in patients with AD (18.03±10.8) than in controls (14.43±4.48;p<0.0001) and MCI (14.15±4.09; p<0.0001).
Apo E 4 allele | The distribution of ApoE4 allele was sig higher in the AD population (p<0.0001) than in controls and MCI (p<0.0001)

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Sr | Folate | ng/ml | p | Sr | B12 | pg/mL | p
| | Mean | SD | r= | | Mean | SD | r=
Probable AD | 99 | 8.5 | 3.38 | NA | NS | 316.7 | 139.5 | | <0.05*
Mild cognitive impaired (MCI) | 98 | 10.87 | 3.93 | ND | NS | 386.3 | 158.7 | | NS
Cognitive intact Healthy elderly | 100 | 7.56 | 5.39 | | | 413.5 | 241.3

* Compared to Cognitive intact healthy elderly

Correlation

Author, Year: Robins Wahlin, 2001 | Ref ID: 2741 | Vitamins: B12, folate
Objective: To provide further evidence of the presence and extent of vitamin-related effects on cognitive performance in old age

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 85.5 (5) | 83.9 ( | Cases: | Cases: | AD: | NA
| Comparative | %Male: | 18% | 21% | All 75 yrs and above, and residents living in the Kungsholmen parish in Stockholm, Sweden and were assessed in 2 phases for inclusion. A random sample of those with an MMSE score above 23 were assessed in phase 2 with extensive examinations | All demented subjects, psychiatric patients or with psychiatric diagnosis, visual disabilities, not screened for vit B12, folate status, on vitamin supplement meds, and those who did not complete the cognitive tests. Subjects with intake of anticonvulsants, anti-metabolites, and trimethoprim and other anti-folate meds
| Prospective | Race: | Probably white 100% | Probably white 100% | | | PD: | NA
Country: | Sweden | Other: | | | Controls: | Controls: | VascDz: | NA
Setting: | Community | | | | Same as above, the controls were selected from those with normal B12 and folate | Same as above | Other:
Funding: Gov, private, non-industry (multiple sources) | | | | | | | Subjects were categorized according to the vitamin status
Comments: Subjects were grouped into vitB12 and/or Folate deficient and controls were both vit B12 and folate normal

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Vit B12 blood level | 200 pmol/L | Clock setting and reading | Drawing and reading clock times with clock faces with marks at number location and no numbers marked | N enrolled: | 230 | 104 | 126
Folate blood level | 11 nmol/L | Trail making test A and B, accuracy Trail making test A and B, time | A shortened version of the TMT from the Halstead Reitan Battery; part A had a max score of 12 and part B had a max score of 11. Accuracy and number of seconds needed to finish each part were registered with unlimited performance time | N analyzed: | 230 | 104 | 126
| | | | Drop-outs (%): | 0%
| | Digit span forward and backward | Administered using WAIS-R criteria
| | Verbal fluency tests
Comments: Analyzed with ANOVA and regression analysis Vit B12 and folate assessed using radioimmunoassay method with cut-offs 200 pmol/L and 11 nmol/L respectively

Other predictors/outcomes reported: | MMSE
Follow-up duration (if applicable): | NA
Reasons for drop out (if applicable): | NA
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
Clock test | No significant main or interaction effects
Block design* | Main effects of B12, F (1,226)=5.33, MSE=40.96, P<0.05, ω2=0.02; groups with lower levels of vit B 12 performed worse than the groups with normal vitamin levels
| Main effects of folate, F (1,226)=24.85, MSE=40.96, P<0.0005, ω2=008; groups with lower of vit folate performed worse than the groups with normal vitamin levels
| Significant association between B12 and Block design performance (paced: beta=0.19; P<0.01; self-paced: beta=0.15, P<0.05)
Trail making test A | No reliable effects either accuracy or time
Trail making test B | Significant main effects of FA on accuracy, F (1,226)=9.13, MSE=7.07, P<0.01, ω2=0.03
| Significant main effects of FA on time, F (1,226)=7.68, MSE=11 114.19, P<0.01, ω2=0.03
| The low folate values were associated with lower performance
| The effect of B12 and the interaction effect were not significant
Digit span forward* | No reliable or interaction effects
Digit span backward* | Significant main effects of FA on accuracy, F (1,226)=8.47, MSE=1.05, P<0.01, ω2=0.03
| The low folate values were associated with lower performance
| The effect of B12 and the interaction effect were not significant
Verbal fluency test | Significant effects for both B12 P<0.01and folate P<0.05

* Part of Wechsler Adult Intelligence Scale

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | N B12/N folate | | p | N | L B12/N folate | | p | N B12/L Folate | | P | L B12/L folate | | p
| | Mean | SD | | | Mean | SD | | Mean | SD | | Mean | SD
MMSE | 126 | 27.46 | 2.22 | Nd | | 26.5 | 2.76 | nd | 26.26 | 2.26 | nd | 25.64 | 2.56 | nd

Correlation

Author, Year: Scileppi, 1984 | Ref ID: 10016 | Vitamins: B1, B2, B6, B12, Folate
Objective: Compare vitamin levels in AD v non-AD

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | nd | | Cases: | Cases: | AD: | nd
| Comparative | %Male: | nd | | Series of subjects coming to a subspecialty dementia clinic in a prosperous suburb. Diagnosed with AD.
| Prospective | Race: | nd | | | | PD:
Country: | US | Other: | | | Controls: | Controls: | VascDz:
Setting: | Dementia clinic | | | | Same as cases, except diagnosed with condition other than AD (implied only). | | Other:
Funding: Industry, Non-Profit | | | | | Controls = Normal (intellectually intact, n=10), Multi-infarct dementia (n=28), Other dementias (n=8), and Depression (n=12)
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Blood B1* | ng/mL | Dx of AD v Control | nd | N enrolled: | 113 | 55 | 58
Blood B2** | ng/mL | | | N analyzed: | | 54–55 | 58
Blood B6*** | ng/mL
Blood B12**** | pg/mL
Blood folate***** | ng/mL | | | Drop-outs (%):
Comments:

* Analyzed protozoologically. Lower level of normal = 25 ng/mL

** Analyzed protozoologically. Lower level of normal = 110 ng/mL

*** Analyzed protozoologically. Lower level of normal = 29 ng/mL

**** Analyzed protozoologically. Lower level of normal = 105 pg/mL

***** Analyzed with Lactobacillus casei. Lower level of normal = 5.0 ng/mL

Other predictors/outcomes reported: | Other vitamins
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Very limited reporting
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text)

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Bl | B1 | ng/mL | N | Bl | B2 | ng/mL | N | Bl | B6 | ng/mL | N | Bl | B12 | pg/mL | N | Bl | Folate | pg/mL
| | Mean | SEM | P | | Mean | SEM | P | | Mean | SEM | P | | Mean | SEM | P | | Mean | SEM | P
AD | 55 | 46 | 4 | NS | 55 | 295 | 10 | NS | 54 | 44.9 | 6.3 | NS | 55 | 290 | 31 | NS | 55 | 11.7 | 1.5 | NS
Control (non-AD) | 58 | 48 | 4 | | 58 | 292 | 9 | | 58 | 38.2 | 2.4 | | 58 | 533 | 25 | | 58 | 10.7 | 1.0

Univariate analyses.

No explanation for large difference in B12, with relatively small SEM, but NS difference.

Correlation

Author, Year: Serot, 2001 | Ref ID: 2933 | Vitamins: B6, B12, Folate
Objective: Evaluation of choroids plexus dysfunction, thus folate levels

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 75.9+/-6.6 | I. 40.6+/-11.3 | Cases: | Cases: | AD: | NINCDS-ADRDA
| | | | II.72.7+/-7.0 | All CSF samples obtained by lumbar puncture, performed to rule out such neurological diseases as CNS infection, subarachnoid hemorrhage, or for diagnostic myelography. Samples contained <0.06 g/L protein and <3 cells/mL.
| Non-comparative | %Male: | 37% | I. 52% | By review or medical records, divided into 3 groups:
| | | | II. 28% | III. AD, >60 y
| Retrospective | Race: | nd | nd | | | PD:
Country: | France | Other: | | | Controls: | Controls:
Setting: | Mixed | | | | I. Normal mentally healthy adults 20–60 y | | Other:
Funding: Government, Non-profit | | | | | II. Normal, mentally healthy elderly >60 y
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
CSF Folate* | ng/mL | AD v non-AD | | N enrolled: | 126 | 30 | I. 60 | II. 36
Serum Folate* | ng/mL | MMSE | | N analyzed: | 126 | 30 | I. 60 | II. 36
| | | | N analyzed (serum): | | 30 | I. 24 | II. 28
Comments:

* Sanofi Diagnostics Pasteur: Access Immunoassay System. ND on normal values.

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text)
MMSE | In group III (AD), CSF-folate levels varied with the severity of dementia with a “slight correlation” (r=0.35)

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | CSF | Folate | ng/mL | p | N | Serum | Folate | ng/mL | p
| | Mean | SD | r= | | | Mean | SD | r=
AD (III) | 30 | 8.26 | 1.82 | | <0.001 | 30 | 5.35 | 2.15 | | NS
Healthy young (I) | 60 | 10.47 | 1.93 | | NS | 24 | 5.31 | 1.73
Healthy elderly (II) | 36 | 9.96 | 2.01 | | | 28 | 5.81 | 2.13

Correlation

Author, Year: Seshadri, 2002 | Ref ID: 2936 | Vitamins: B12, folate, B6
Objective: To examine the relation between plasma tHcy levels and newly diagnosed AD in elderly population-based cohort

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Longitudinal | Age: | 76 ± 6 (range 68–97) | N/A | Cases: | Cases: | AD: | NINCDS/ARDRA
| Non-comparative | %Male: | 39 | N/A | Subjects enrolled in a dementia-free cohort between 1976-78, who underwent their 20^th^ biennial examination between 1986-90 and had Hcy levels measured | ND
| Prospective | Race: | ND | N/A | | | PD:
Country: | US | Other: | | | Controls: | Controls: | VascDz: 11 | ND
Setting: | community | | | | N/A | N/A | Other: | DSM-IV
| | | | | | | Non-AD degenerative dementia: 11; other types:6
Funding: government
Comments: Framingham Study participants

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
B12, Folate, B6 | Dementia | | N enrolled: | 1092 | 111 | N/A
B12, Folate, B6 | AD | | N analyzed: | 1092 | 83 | N/A
| | | Drop-outs (%): | 0 | 0 | N/A
Comments: | Of the total population N=1092, 85% had measurements for B12, 92% for B6, and 98% for folate; not reported how many of these patients with B12, B6, and folate measurements developed dementia and/ or AD
| Plasma folate was measured by amicrobial (Lactobacillus casei) assay with a 96-well plate and manganese supplementation
| Plasma B12 levels were estimated with the use of a radioassay kit (Magic, Ciba-Corning, Medfield, Mass)
| B6 (PLP) was measured by the tyrosine decarboxylase apoenzyme method (REF 32)
| Coefficients of variation for these assays were 13% for plasma folate, 7% for B12, and 16% for PLP

Other predictors/outcomes reported: | Age, gender, APOE genotype, Hcy levels, education level, cigarette smoking, alcohol intake, DM, SBP, BMI
Follow-up duration (if applicable): | Median 8 yr (range 1–13)
Reasons for drop out (if applicable):
Limitations: | Race info not given; results for B12, B6, and folate and their relation to AD /dementia not reported
Quality (A/B/C): B | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
Dementia, AD | After adjusting for age, sex, and APOE genotype none of the Vit levels (B12, folate, B6) were independently related to the risk of dementia or AD

Correlation

Author, Year: Shahar, 2001 | Ref ID: 2940 | Vitamins: Vit B12
Objective: To determine the prevalence of low and low normal vitamin B12 levels in “sick” elderly subjects hospitalized in a geriatric medical center and analyzed the relationship of vitamin B12 levels to several clinical parameters

Study characteristics | | Population* | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 78(8) | | Cases: | Cases: | AD:
| Non-comparative | %Male: | 46% | | Patients of either gender who were ≥65 yrs old and were discharged from the hospital or died in the hospital between Jan 1 and Dec 31 1996 and included those who had sr vit B12 analyzed once during hospital stay and whose last name commenced with one of the first 12 letters of the Hebrew alphabet | As inclusion criteria
| Retrospective | Race: | Probably white | | | | PD:
Country: | Israel | Other: | | | Controls: | Controls: | VascDz:
Setting: | Academic hospital | In-hospital death | 38.3% males and 35.9% for females | | None | | Other:
Funding: ND | | | | | | | Cognitive impairment | ND
Comments: Though comparative in the study none of the comparative groups were eligible as controls for this data extraction

* Data available for men and women separately

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest (cog impaired) | Control
Vitamin B12 levels-low | <150 pmol/L | Cognitive impairment | ND | N enrolled: | 640 | 37.2%
Vitamin B12 levels-borderline | 150–250 pmol/L | | | N analyzed: | 640 | 37.2%
Vitamin B12 levels-normal | >250 pmol/L | | | Drop-outs (%): | 0
Comments:

Sr B12 measured by “access” immunoassay system

Other predictors/outcomes reported: | Folic acid levels correlating with vit B12 levels (not data extracted as no separate subgroup analysis available); % treated for vitamin deficiency
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Poor sampling; no definition of cognitive impairment;
Quality (A/B/C): C | Applicability (1/2/3): 1

Outcome(s): | Results (Text)

Correlation of Predictors with Outcomes (cross-sectional studies)-Among cognitive impaired only for this study

Description of (Sub-) Groups | N | Sr | B 12 vit | pmol/L | p
Cognitive impairment | | Mean | SE/SD | %
Low B12 <150 pmol/L | | | | 46.9%
Borderline B12 150 to 250 | | | | 36.4%
Normal >250 | | | | 35.7%
Total cognitive impaired | 238 | | | | Unadjusted P=NS Adjusted P=0.04

Correlation

Author, Year: Snowdon, 2000 | Ref ID: 3059 | Vitamins: Folate
Objective: To investigate the relation between serum folate and the severity of atrophy of the neocortex at autopsy; to investiaget if low serum folate would have a strong association with atrophy of the nerocortex with an atrophic disease process like AD.

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 91 y (died) | | Cases: | Cases: | AD: | Neuropathology definitions: neurofibrillary tangle, senile plaques and neuritic plaques per mm^2^ microscopic field
| Comparative | %Male: | 0 | | 30 nuns who died 2 to 55 mo (average 24 mo) after serum folate measurements were taken.
| Retrospective | Race: | white | | | | PD:
Country: | US | Other: | | | Controls: | Controls: | VascDz:
Setting: | convent | | | | 65 survivors | | Other:
Funding: National Institute on Aging, Abercrombie Foundation & the Kleberg Foundation
Comments:

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
Folate | Neocortex Atrophy | | N enrolled: | 30 | 30
Vitamin B-12 | Number of AD lesions | | N analyzed: | 30 | 30
Vitamin B-6 | | | Drop-outs (%): | 0 | 0
Thiamine
Comments: only histopathological diagnoses of AD reported in this study; no clinical correlation

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 3 1

Outcome(s): | Results (Text)
| Among all 30 participants, the age-adjusted correlation of serum folate with the severity of atrophy was -0.40 (p=0.03).
| Among the subset of 15 subjects with significant number of AD lesions, the age-adjusted correlation between folate and the severity of atrophy was -0.80 (p=0.0006). None of the other nutrients were significantly correlated with the severity of atrophy of the neocortex.
| The severity of atrophy of the neocortex was significantly correlated with the mean number of neurofibrillary tangles in the subset of pts with signficant number of AD lesions (r=0.54, p=0.048). Serum folate was not significantly correlated with the mean number of neurofibrillary tangles in the neocortex (r= -0.14, p=0.63).
| Regression analyses for the subset of 12 subjects indicated that folate had a signficant inverse association with cognitive function after adjustment for age and the number of neurofibrillary tangles: a 10-nmol/L decrease in serum folate was associated with a 1-point decrease in the score for the MMSE (p=0.04).

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Sr | folate | nmol/L | p | Sr | B-12 | nmol/L | p | Sr | B-6 | nmol/L | | Sr | Thiamine | nmol/L | p
| | Mean | SD | r= | | Mean | SD | r= | | Mean | SD | r= | | Mean | SD | r=
(+) Significant number of AD lesions | 15 | 45 | 52 | -0.80 | <0.001 | 119 | 58 | -.19 | NS | 319 | 189 | -0.38 | NS | 142 | 36 | -0.49 | NS
Without signficant number of AD lesions | 15 | 61 | 54 | .14 | NS | 128 | 94 | -.08 | NS | 290 | 65 | .03 | NS | 148 | 30 | .05 | NS

Correlation

Author, Year: Stewart, 2002 | Ref ID: 3133 | Vitamins: Plasma homocysteine
Objective: To investigate the association between homocysteine concentrations and cognitive impairment in an older African-Caribbean population

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 65 (n=238?) | | Cases: | Cases: | AD:
| Comparative | %Male: | 47% (n=238?) | | 248 participants with plasma homocysteine data and born in a Caribbean nation
| Retrospective | Race: | African/Caribbean descent | | | | PD:
Country: | UK | Other: | | | Controls: | Controls: | VascDz:
Setting: | Primary care services | | | | | | Other:
Funding: Wellcome Trust
Comments: Discrepancy between n=238 in table 1 and text description of n=248

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
Highest quartile of homocysteine concentration (>13.85 micromol/L) | Cognitive impairment | Yes or No | N enrolled: | 248
| | | N analyzed: | 248
| | | Drop-outs (%):
Comments: 11 psychometric tests drawn from the Consortium to Establish a Registry for Alzheimer's Disease and WHO batteries; subjects were categorized as having relative cognitive impairment on the basis of scores <30%tile on 6 or more tests, or <10%tile on 4 or more tests.

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 2 2

Outcome(s): | Results (Text)
| Cognitive impairment was classified in 68 (27%) participants. Raised homocysteine (highest quartile: >13.85 micromol/L) was associated with cognitive impairment (OR=2.50, 95% CI = 1.33 to 4.69). This association persisted after adjustment for age, occupation, other measures of vascular risk, folate, BMI and waist:hip ratio (OR=3.00, 95% CI = 1.35 to 6.69). As with other risk factors for vascular disease in this sample, the association was significant only in those with less education (p-value for interaction=.049). This association was independent of other measures of vascular risk and was not explained by folate concentrations.

Description of (Sub-) Groups | N | Cognitive impairment
| | OR | OR (Adjusted for age, occupation, other measures of vascular risk, folate, BMI and waist:hip ratio )
Homocysteine ≤ 13.85 micromol/L | 180 (?)
Homocysteine >13.85 micromol/L | 68 | OR=2.50, 95% CI = 1.33 to 4.69 | OR=3.00, 95% CI = 1.35 to 6.69

Correlation

Author, Year: Stuerenburg, 2004 | Ref ID: 3150 | Vitamins: B12
Objective: To investigate the correlation between plasma B12 levels and cognitive impairment in AD patients

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 71.8 ±SD 8.5 | N/A | Cases: | Cases: | AD: | NINCDS/ARDRA criteria (REF 6)
| Comparative | %Male: | 45 | N/A | Patients with AD | ND
| Retrospective | Race: | | | | | PD:
Country: | Germany | Other: | | | Controls: | Controls: | VascDz:
Setting: | ND | | | | N/A | N/A | Other:
Funding: ND
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
B12 | | MMSE score | ND | N enrolled: | ND | ND
B12 | Lower percentile (<184ng/mL) | MMSE score | ND | N analyzed: | ND | ND
B12 | Upper percentile (>598ng/mL) | MMSE score | ND | Drop-outs (%): | N/A
Comments:

Other predictors/outcomes reported: | age
Follow-up duration (if applicable): | N/A
Reasons for drop out (if applicable): | N/A
Limitations: | sample not well-described; methods of evaluation (B12, MMSE) not described; results not explicitly reported; confounding factors also not considered (except for age)
Quality (A/B/C): C | Applicability (1/2/3): 1

Outcome(s): | Results (Text)
MMSE scores | NS correlation between plasma B12 and MMSE scores. A significant inverse correlation became apparent when the MMSE score of those patients with the lowest 10% B12 plasma levels were compared with the upper B12 plasma levels (Spearman rho= -0.36, p=0.008)

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | (Sr) | (B 12) | (ng/mL) | p | (Sr/CSF) | (B vit) | (unit) | p | (Sr/CSF) | (B vit) | (unit) | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | SE/SD | r= | | Mean | SE/SD | r= | | Mean | SE/SD | r= | Mean | SE/SD | r=
All subjects (B12 compared to MMSE scores); Spearman rank correlation | 241 | 371 | 216 | ND | 0.38
Subjects with B12<184ng/mL | ND | 15.7 | 6.1 | -0.36 | 0.008
Subjects with B12>598ng/mL | ND | 20 | 4.6

Correlation

Author, Year: Teunissen, 2003 | Ref ID: 3239 | Vitamins: B12, folate
Objective: To investigate whether elevated serum tHcy is a risk factor for cognitive decline

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Longitudinal | Age: | 57 ± 11 | N/A | Cases: | Cases: | AD:
| Non-comparative | %Male: | 59 | N/A | Normal aging subjects of MAAS (Maastricht Aging Study) were randomly drawn from the Registration Network Family Practices; baseline medical and neuropsychological examination in 1993; | Evidence of past or present morbidity that may compromise brain function, such as cerebrovascular disease (including stroke), chronic neurological pathology (e.g., dementia, epilepsy or PD), mental retardation or chronic psychotropic drug use
| Prospective | Race: | | | | | PD:
Country: | The Netherlands | Other: | | | Controls: | Controls: | VascDz:
Setting: | community | | | | N/A | N/A | Other:
Funding: Non-profit
Comments: For a number of participants (those who did not have available serum sample at baseline) age and gender are not reported

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
B12, folate | Patients with available B12, folate at baseline | World Learning Test (WLT); Delayed Recall Test | Based upon the Auditory Verbal Learning Test (REF 35); evaluates the ability to acquire and retain verbal info. | N enrolled: | 93 | 93 | N/A
B12, folate | Patients with available B12, folate at baseline | Letter-Digit Coding Test (LDCT) | Paper-and-pencil test is a modified version of the Symbol Digit Modalities Test (REF 36) and measures info processing speed. | N analyzed: | 92 | 92 | N/A
B12, folate | Patients with available B12 at baseline | STROOP Color-Word Test | Subtask III involves color names but the printing ink is different from the color name. Only the data of subtask III are used in the current study | Drop-outs (%): | 1 | 1 | N/A
Comments: B12, folate were measured using commercial kits (Bayer Immuno 1, Leverkusen, Germany)

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
B12 | Patients with available B12 either at baseline or during follow-up | World Learning Test (WLT); Delayed Recall Test | Based upon the Auditory Verbal Learning Test (REF 35); evaluates the ability to acquire and retain verbal info. | N enrolled: | 115 | 115 | N/A
B12 | Patients with available B12 either at baseline or during follow-up | Letter-Digit Coding Test (LDCT) | Paper-and-pencil test is a modified version of the Symbol Digit Modalities Test (REF 36) and measures info processing speed. | N analyzed: | 114 | 114 | N/A
B12 | Patients with available B12 either at baseline or during follow-up | STROOP Color-Word Test | Subtask III involves color names but the printing ink is different from the color name. This test shows robust effects of chronological age (REF 37). Only the data of subtask III are used in the current study | Drop-outs (%): | 1 | 1 | N/A
Comments: B12 were measured using commercial kits (Bayer Immuno 1, Leverkusen, Germany)

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
folate | Patients with available folate either at baseline or during follow-up | World Learning Test (WLT); Delayed Recall Test | Based upon the Auditory Verbal Learning Test (REF 35); evaluates the ability to acquire and retain verbal info. | N enrolled: | 115 | 115 | N/A
folate | Patients with available folate either at baseline or during follow-up | Letter-Digit Coding Test (LDCT) | Paper-and-pencil test is a modified version of the Symbol Digit Modalities Test (REF 36) and measures info processing speed. | N analyzed: | 111 | 111 | N/A
folate | Patients with available folate either at baseline or during follow-up | STROOP Color-Word Test | Subtask III involves color names but the printing ink is different from the color name. This test shows robust effects of chronological age (REF 37). Only the data of subtask III are used in the current study | Drop-outs (%): | 4 | 4 | N/A
Comments: Folate was measured using commercial kits (Bayer Immuno 1, Leverkusen, Germany)

Other predictors/outcomes reported: | Hcy, age, gender, level of eduaction
Follow-up duration (if applicable): | 6 yr
Reasons for drop out (if applicable): | insufficient serum measurements
Limitations: | Part of the population not described (age, gender); power calculations not reported
Quality (A/B/C): B | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
World Learning Test (WLT); Delayed Recall Test | Based upon the Auditory Verbal Learning Test (REF 35); evaluates the ability to acquire and retain verbal info. The total number of correctly reproduced words on the 5 immediate recall trials is recorded (WLTTOT). After 20 min the subject is asked to reproduce the set of words (Delayed Recall) (REF 31). Higher score reflects better cognitive performance
Letter-Digit Coding Test (LDCT) | Paper-and-pencil test is a modified version of the Symbol Digit Modalities Test (REF 36) and measures info processing speed. The total number of correctly copied corresponding numbers in 90 sec is recorded as test outcome. Higher score reflects better cognitive performance
STROOP Color-Word Test | The test examines the speed at which color names are read (subtask I) and the speed at which color spots are named (subtask II). Subtask III involves color names but the printing ink is different from the color name. The time needed to name the color of the printing ink of the words is recorded. Lower score reflects better cognitive performance. This test shows robust effects of chronological age (REF 37). Only the data of subtask III are used in the current study

Correlation of Predictors with Outcomes (zero order correlation, Spearman correlation coefficients); STROOP test

Description of (Sub-) Groups | N | (Sr) | (B 12) | (ng/L) | p | (Sr) | (folate) | (mg/L) | p | (Sr/CSF) | (B vit) | (unit) | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | SE/SD | r= | | Mean | SE/SD | r= | | Mean | SE/SD | r= | Mean | SE/SD | r=
Patients with available B12, folate at baseline | 92 | 406 | | -0.168 | NS | 3.9 | | -0.126 | NS
Patients with available B12 either at baseline or during follow-up | 114 | 396 | | -0.102 | NS
Patients with available folate either at baseline or during follow-up | 111 | 5 | | -0.066 | NS

LDCT

Description of (Sub-) Groups | N | (Sr) | (B 12) | (ng/L) | p | (Sr) | (folate) | (mg/L) | p | (Sr/CSF) | (B vit) | (unit) | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | SE/SD | r= | | Mean | SE/SD | r= | | Mean | SE/SD | r= | Mean | SE/SD | r=
Patients with available B12, folate at baseline | 92 | 406 | | 0.031 | NS | 3.9 | | 0.085 | NS
Patients with available B12 either at baseline or during follow-up | 114 | 396 | | 0.081 | NS
Patients with available folate either at baseline or during follow-up | 111 | 5 | | 0.042 | NS

WLTTOT

Description of (Sub-) Groups | N | (Sr) | (B 12) | (ng/L) | p | (Sr) | (folate) | (mg/L) | p | (Sr/CSF) | (B vit) | (unit) | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | SE/SD | r= | | Mean | SE/SD | r= | | Mean | SE/SD | r= | Mean | SE/SD | r=
Patients with available B12, folate at baseline | 92 | 406 | | 0.075 | NS | 3.9 | | 0.037 | NS
Patients with available B12 either at baseline or during follow-up | 114 | 396 | | -0.008 | NS
Patients with available folate either at baseline or during follow-up | 111 | 5 | | -0.080 | NS

Delayed recall

Description of (Sub-) Groups | N | (Sr) | (B 12) | (ng/L) | p | (Sr) | (folate) | (mg/L) | p | (Sr/CSF) | (B vit) | (unit) | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | SE/SD | r= | | Mean | SE/SD | r= | | Mean | SE/SD | r= | Mean | SE/SD | r=
Patients with available B12, folate at baseline | 92 | 406 | | 0.055 | NS | 3.9 | | 0.214 | <0.05
Patients with available B12 either at baseline or during follow-up | 114 | 396 | | 0.011 | NS
Patients with available folate either at baseline or during follow-up | 111 | 5 | | -0.151 | NS

Unstandardized regression coefficients (95%CIs) of B12, folate adjusted for individual baseline age, sex, and educational level

Description of (Sub-) Groups | N | STROOP test | | LDCT | | WLTTOT | | Delayed recall
| | b coefficient (Adj 1*) | | b coefficient (Adj 1*) | | b coefficient (Adj 1*) | | b coefficient (Adj 1*)
Patients with available B12 at baseline | 92 | 4.24 | -22.92, 31.39 | -7.66 | -17.19, 1.86 | 0.70 | -8.93, 10.33 | -0.21 | -3.46, 3.04
Patients with available folate at baseline | 92 | -2.31 | -4.98, 0.37 | 0.54 | -0.42, 1.51 | 0.34 | -0.63, 1.3 | 0.32** | 0.01, 0.64
Patients with available B12 either at baseline or during follow-up | 114 | -0.69 | -32.75, 31.37 | -3.26 | -11.47, 4.95 | -1.17 | -9.28, 6.93 | -0.23 | -2.75, 2.29
Patients with available folate either at baseline or during follow-up | 111 | -0.27 | -3.03, 2.5 | -0.05 | -0.74, 0.65 | -0.47 | -1.14, 0.21 | -0.16 | -0.37, 0.05

* Adj 1, adjusted for age, sex, and educational level

** p<0.05; all other comparisons NS

Correlation

Author, Year: Tripathi, 2001 | Ref ID: 733 | Vitamins: B12
Objective: Review of B12 status in dementia

Study characteristics | | Population | | Controls* | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 61.6+/-6.6 | 60.2+/-6.6 | Cases: | Cases: | AD: | DSM-IV, NINCDS-ADRDA
| Comparative | %Male: | | | Seen in cognitive disorders clinic, documented cobalamin level (Prospective n=54, Retrospective n=56)
| Pro/Retrospective | Race: | | | | | PD:
Country: | India | Other: | | | Controls: | Controls: | Vascular dementia: | NINCDS-ARIEN
Setting: | Clinic | | | | | | Other:
Funding: nd
Comments:

* Vascular or other dementias

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control**
Serum B12* | pg/mL | Diagnosis of AD | | N enrolled: | | 38 | 62
| | | | N analyzed: | | 38 | 62
| | | | Drop-outs (%):
Comments:

* Micropore enzyme immunoassay (MPEIA). Normal: 187–1057 pg/mL; Indeterminate: 157–187 pg/mL; Low: <157 pg/mL.

** Vascular or other dementias

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Mixture of prospective and retrospective
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text)

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Serum | B12 | Low* | p | Serum | B12 | pg/mL | p
| | n | % | | | Mean | SD
AD (probably/possible) | 38 | 15 | 39.5% | | <0.05 | 263 | 168 | | <0.05
Vascular and other dementias* | 62 | 8 | 12.9% | | | 289 | 139

* <187 pg/mL, implied

** Including mixed, diffuse Lewy body disease, infections, nutritional, head injury, systemic, extra-pyramidal, etc.

Correlation

Author, Year: Wahlin, 1996 | Ref ID: 3433 | Vitamins: B12, folate
Objective: To examine the relationship between low B12 (<200 pmol/L) and folate (<11 nmol/L), separately and combined, and episodic memory performance in very old age

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 85 | | Cases: | Cases: | AD:
| Comparative | %Male: | 18% | | Nondemented elderly | Psychiatric dx; no B-12 or folate levels; on B-12 or folate, drugs interfere with folate uptake; on neuroleptics & antidepressants without a psychiatric dx
| Prospective | Race: | white | | | | PD:
Country: | Sweden | Other: | | | Controls: | Controls: | VascDz:
Setting: | Lived in Kungsholmen district in Stockholm | | | | | | Other:
Funding: Predoctoral fellowship grants
Comments:

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
Normal B-12, normal folate | Free-Recall performance | 2 memory lists of 12 concrete nouns; one list presented at a rate of 2 seconds/word, and the other presented at a rate of 5 seconds/word; subjects were told to remember as many words as possible for subsequent free-recall tests | N enrolled: | 250
Low B-12 (<200 pmol/L), normal folate | Recognition test | After free-recall of each list, yes-no recognition tests were given, in which 12 target words were presented intermixed with an equal number of detractors; participants responded orally | N analyzed: | 250
Normal B-12, low folate (<11 nmol/L) | | | Drop-outs (%): | 0
Low B-12, low folate
Comments:

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): B | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
| Free Recall: Normal B-12, normal folate group performed better than Low B-12, low folate group and Normal B-12, low folate (<11 nmol/L) group by ANOVA (p<.01)
| Recognition: Normal B-12, normal folate group performed better than Low B-12, low folate group and Normal B-12, low folate (<11 nmol/L) group by ANOVA (p<.01). No significant interaction effects between vitamin group and study time in the ANOVAs
| Contrasting results from the analyses in which vitamin status was used as a categorical variable and those in which it was used as a continuous variable suggest that vitamin B12 and folate may affect episodic memory functioning only among those individuals whose vitamin levels are relatively low.

Correlation

Author, Year: Wang, 2001 | Ref ID: 3445 | Vitamins: B12, folate
Objective: To explore whether low serum levels of vitamin B12 and folate constitute risk factors for dementia, in particular for AD

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Longitudinal | Age: | | | Cases: | Cases: | AD: | Clinical onset and DSM III
| | 75–79 | n=81
| | 80–84 | n=97
| | 85–89 | n=119
| | 90–101 | n=73
| Non-comparative | %Male: | 19% | | All non demented and those without a vitamin treatment and participated in the Kungsholmen project (a large longitudinal population based study) on aging and dementia that included all inhabitants born in 1912 or earlier and lived in one area of Stockholm on October 1987. | Those who were demented and taking B 12 or folate supplementation and vascular dementia
| Prospective | Race: | Probably 100% white | | | | PD:
Country: | Sweden | Other:Education >7 yr | 36% | | Controls: | Controls: | VascDz: | Clinical and Hachinski's scale
Setting: | Academic hospital | Alcohol consumption | 78% yes | | None | | Other:
Funding: Private foundations; partly gov
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
Vitamin B12 | pmol/L | | | N enrolled: | 370
Folate | nmol/L | | | N analyzed:
| | | | Drop-outs (%):
Comments: 2 different cutoffs were used to define folate and B12 deficiency. For B12 the lower and higher cut-off points were 151–252 pmol/L were used; and for folate it was ≤10 and ≤12 nmol/L was chosen

Other predictors/outcomes reported:
Follow-up duration (if applicable): | 3 years
Reasons for drop out (if applicable):
Limitations: | 2 different cut-offs
Quality (A/B/C): B | Applicability (1/2/3): 3

Outcome(s): | Results (Text)

Prevalence of B12 and folate deficiency at baseline (cross-sectional studies) At baseline

Description of (Sub-) Groups | N | Sr | B12 | ≤150 pmol/L n=58 | p | Sr | B12 | ≤250 pmol/L n=175 | p | Sr | Folate n=54 | ≤10 nmol/L | P | Sr | Folate n=105 | ≤12 nmol/L | p
| | Mean | SE/SD | Prevalence | | Mean | SE/SD | Prevalence | | Mean | SE/SD | Prevalence | | Mean | SE/SD | Prevalence
MMSE score ≤ 26 | 173 | nd | | 17.3% | NS | nd | | 52.6% | NS | nd | | 22.1% | <0.01 | nd | | 35.5% | <0.01
MMSE score > 26 | 197 | nd | | 14.2% | | nd | | 42.6% | | nd | | 8.2% | | nd | | 22.4%

Number of incident cases(n) and relative risks (RR) of Alzheimer's disease and dementia in relation to baseline vitamin levels

Description of (Sub-) Groups | N | Alzheimer's disease | | | | N | Dementia
| | Crude RR (95% CI) | | RR (Adj 1*) (95% CI) | | | Crude RR (95% CI) | | RR (Adj 1*) (95% CI)
B12 ≤150 vs >150 pmol/L | 14 vs 46 | 1.7 | (0.9–3.1) | 1.6 | (0.9–2.8) | 15 vs 63 | 1.4 | (0.8–2.4) | 1.3 | (0.7–2.3)
Folate ≤10 vs >10 nmol/L | 12 vs 47 | 1.8 | (1.0–3.4) | 1.7 | (0.9–3.2) | 15 vs 62 | 1.7 | (1.0–3.0) | 1.6 | (0.9–2.9)
B12 ≤150 or folate ≤10 nmol/L vs normal levels of both B12 and folate | 26 vs 34 | 2.3 | (1.47–3.8) | 2.1 | (1.2–3.5) | 30 vs 48 | 1.9 | (1.2–3.0) | 1.8 | (1.1–2.8)

Adj 1, adjusted for age sex and education...

AD association with 2 levels of vitamin B12 or folate

Description of (Sub-) Groups | N | Alzheimer's disease
| | RR (Adj 1*) | | RR (Adj 2*)
(Reference gp) Normal levels of both vitamins | 34/268 | 1 | | 1
Low B12 and normal folate levels | 13/47 | 0.7 | (0.1–5.4) | 0.6 | (0.1–4.4)
Low folate and normal B12 levels | 11/43 | 2.1 | (1.1–4.1) | 1.7 | (0.9–3.3)
Low levels of both vitamins | 1/11 | 2.3 | (1.2–4.6) | 1.2 | (0.5–2.5)
(Reference gp) Normal levels of both vitamins | 34/268 | 1 | | 1
Low levels of vit B12 or folate | 25/101 | 2.1 | (1.2–3.5) | 1.4 | (0.8–2.4)

Adj 1, adjusted for age sex and education...

Adj 2, adjusted for age, sex, education and cognitive functioning...

Association of vitamin levels vs normal levels stratified by cognitive functioning

Description of (Sub-) Groups | N | Alzheimer's disease Those with MMSE score ≤26
| | OR (Adj 1*) | | OR (Adj 2*)
(Reference gp) Normal levels of both vitamins | 25/112 | 1 | | 1
Low B12 or folate levels | 18/60 | 1.5 | (0.87–2.7)
| | Alzheimer's diseaseThose with MMSE score >26
(Reference gp) Normal levels of both vitamins | 9/156 | 1 | | 1
Low B12 or folate levels | 7/41 | 3.1 | (1.1–8.4)

Correlation

Author, Year: Whyte, 2002 | Ref ID: 3509 | Vitamins: B12
Objective: To examine the relationship between B12 serum levels and cognitive and neuropsychiatric symptoms in dementia

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 78.9±7.73 | 75.1±7.84 | Cases: | Cases: | AD:643 | NINCDS-ADRDA criteria
| Comparative | %Male: | 30 | 32 | Community dwelling elderly patients who consecutively evaluated in a University Clinic between Sep 1991 and June 1999 and were found to have probable or possible AD; Low B12 ≤ 200pg/mL | ND
| Prospective | Race: | White 97% | White 90% | | | PD:
Country: | US | Education, yr | 12.9±3.88 | 11.9±3.03 | Controls: | Controls: | VascDz:
Setting: | University Clinic (outpatients) | | | | Community dwelling elderly patients who consecutively evaluated in a University Clinic between Sep 1991 and June 1999 and were found to have probable or possible AD; Normal B12 ≥ 201pg/mL | ND | Other:
Funding: ND
Comments: Mean age was significantly different between the 2 groups (p=0,01)

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
B12 | Low ≤ 200 pg/mL | Folstein MMSE, Mattis DRS, CDR scale, CERAD BRSD, Hachinski scale, Modified Rey Figure Copy, Immediate, and Delayed Recall, Verbal Fluency, Benton Visual Form Discrimination, world List Learning with Immediate and Delayed Recall | | N enrolled: | 643 | 37 | 606
| | | | N analyzed: | 643 | 37 | 606
| | | | Drop-outs (%): | N/A | N/A | N/A
Comments: ND on the methods B12 was measured; descriptions of tests are given by REF (18–24, 27–30)

Other predictors/outcomes reported: | Regression techniques for comparing scores between different groups were adjusted for the effects of age and education
Follow-up duration (if applicable): | N/A
Reasons for drop out (if applicable): | N/A
Limitations: | Majority of subjects are white women; power calculations not reported
Quality (A/B/C): B | Applicability (1/2/3): 3

Outcome(s): | Results
| B12 low 2 ≤ 200pg/mL | SD | B12 normal ≥ 201pg/mL | SD | p
Folstein MMSE | 14.73 | 7.33 | 16.94 | 5.66 | 0.01
Mattis DRS | 105.4 | 25.02 | 110.82 | 18.03 | NS
Blessed | 2.63 | 5.07 | 2.27 | 3.88 | 0.02
CDR scale (0) | 1 | 2.7 | 2 | 0.3 | NS
CDR scale (1) | 18 | 48.7 | 385 | 63.7 | NS
CDR scale (2) | 13 | 35.1 | 183 | 30.3 | NS
CDR scale (3) | 5 | 13.5 | 34 | 5.6 | NS
CERAD BRSD (total) | 93.1 | 68.4 | 87.74 | 61.32 | NS
Hachinski scale | 2.97 | 1.72 | | | NS
Modified Rey Figure Copy | 17.46 | 5.61 | 16.03 | 6.64 | NS
Modified Rey Immediate Recall | 1.77 | 2.93 | 1.48 | 4.09 | NS
Modified Rey Delayed Recall (0) | 11 | 44 | 212 | 42 | NS
Modified Rey Delayed Recall (<10) | 15 | 56 | 225 | 50.5 | NS
Modified Rey Delayed Recall (>10) | 0 | 0 | 38 | 7.5 | NS
Verbal Fluency | 8.32 | 3.06 | 9.36 | 4.14 | NS
Benton Visual Form Discrimination | 23.59 | 4.74 | | | NS
World List Learning with Immediate | 3.04 | 1.51 | 2.88 | 2.01 | NS
World List Learning with Delayed Recall | 1.36 | 1.68 | 0.99 | 1.71 | NS

Correlation

Author, Year: Woitalla, 2004 | Ref ID: 3543 | Vitamins: B6, B12 and folate
Objective: To compare levels of B6, B12, folate and total plasma homocysteine (t-hcys) in plasma of levodopa treated PD pts, subdivided by their MTHFR C677T genotypes and controls

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | 65 | 58 (n=44) | Cases: | Cases: | AD:
| Comparative | %Male: | 57% | 51% (n=41) | PD pts only, on levodopa and dopa decarboxylas inhibitors | Metabolic disturbances like diabetes, abnormal vitamin values or vitamin supplementation
| Prospective | Race: | | | | | PD:
Country: | Germany | Other: | | | Controls: | Controls: | VascDz:
Setting: | | | | | | | Other:
Funding:
Comments:

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
PD | t-hcys | | N enrolled: | 127 | 83 | 44
PD with CT allele subgroup | B6 | | N analyzed:
PD with TT allele subgruop | B12 | | Drop-outs (%):
PD with CC allele subgroup | Folate
Comments:

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Text description of results contradict results in tables 1 and 2 (?)
Quality (A/B/C): C | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
| There were significant different t-hcys concentrations in PD pts and controls.
| Concentrations of B6 or B12 did nto differ, but folic acid was significantly higher in PD pts with CT allelele.
| There was no impact of the covariates (sex and age) on the results.

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Plasma | t-hcys | μmol/L | p | Sr | B-6 | mg/L | p | Sr | B-12 | mg/L | Sr | Folate | mg/L | p
| | Mean | SE/SD | | | Mean | SE/SD | r= | | Mean | SE/SD | r= | Mean | SE/SD | r=
PD | 83 | 17.9 | 9.84 | | | 18.7 | 6.69 | | | 371.45 | 218.43 | | 6.39 | 3.31
CT allele | 38 | 14 | 5.7 | CT vs. control | 0.0004 | 20.65 | 7.49 | | | 322.55 | 119.89 | | 7.53 | 3.95
TT allele | 12 | 22 | 8.58 | TT vs. control | 0.03 | 18.25 | 5.72 | | | 369.58 | 172.5 | | 5.54 | 2.79
CC allele | 33 | 20.9 | 12.3 | CC vs. CT | 0.0029 | 16.62 | 5.43 | | | 428.42 | 298.7 | | 5.39 | 2.14
Control | 44 | 13.01 | 5.49 | | | 19.23 | 8.71 | | | 417.86 | 232.95 | | 6.48 | 2.86

Correlation / FFQ

Author, Year: Chen, 2004 | Ref ID: 575 | Vitamins: Folate, B6, B12
Objective: To investigate whether intake of folate or of related B vitamins that are involved in folate and homocysteine metabolism was associated with Parkinson's disease (PD) risk

Study characteristics | | Health Professionals Follow-up Study | | Nurses' Health Study | Inclusion criteria | Exclusion criteria | Definitions
Study design | Longitudinal | Age: | 40–75 | 30–55 | Cases: | Participants who reported PD (n=178), stroke (n=505), or cancer (other than nonmelanoma skin cancer, n=5572), at baseline were excluded from the analyses. In addition, participants with extreme daily energy intakes (<800 or >4200 kcal for men; <500 or >3500 for women) or incomplete FFQ at baseline (>70 blanks for men or >10 for women) were excluded from the analyses. | AD: | ND
| Comparative | %Male: | 100 | 0 | All newly developed PD cases in both Health Professional Follow-up cohort (men) and Nurse's Health cohort (women) from 1986 and from 1980, respectively, to the end of the follow-up (January 31, 2000, in men and May 31, 1998, in women)
| Prospective | Race: | ND | ND | | | PD: | After obtaining permission from participants who reported a new diagnosis of PD, a diagnosis of PD was considered definite or probable by the treating neurologist or internist, or if medical record included either a final diagnosis of PD made by a neurologist or evidence at a neurologic examination of at least 2 of the 3 cardinal signs (rest tremor, rigidity, bradykinesia) in the absence of features suggesting other diagnosis.
Country: | US | Other: | | | Controls: | | VascDz: | ND
Setting: | Population-based (2 large cohorts in US) | | | | All subjects without a diagnosis of PD in the cohorts. | | Other:
Funding: NIH
Comments: 2 nested case-control studies were analyzed separately and then pooled analyses were also performed.

| | Outcome(s): | Definition: | | Total | Population of interest | Control
| | | | N enrolled: | 136,057 | N/A | N/A
Folate intake quintiles | FFQ during the previous 12 months, with 9 possible response categories ranging from “never” to “6 or more times per day.” Information on the dose and duration of supplemental use of specific vitamins and multivitamins was also collected. The nutrient composition of foods was estimated from the Harvard University Food Composition Database that was derived from the US Department of Agriculture and supplemented with information from manufacturers and data from peer-reviewed literature. Validations studies have been done. | RR of PD | Cox proportional hazard models controlling for age, smoking status, caffeine intake, alcohol consumption, and lactose intake. | N analyzed: | 136,057 | 415 | 135,642
Vitamin B6 intake quintiles | | | | Drop-outs (%): | N/A
Vitamin B12 intake quintiles | | | | Note: Original cohort was51,529+121,700. 21% participants were not included in the analyses due to various reasons stated in the exclusion criteria.
Folate supplement use | Nonusers, < 400 μg/day, ≥ 400 μg/day | Pooled RR of PD | Log relative risks (RRs) from the 2 cohorts were pooled by the inverse of their variance.
Vitamin B6 supplement use | Nonusers, < 1.7 mg/day, ≥ 1.7 mg/day
Vitamin B12 supplement use | Nonusers, < 2.4 μg/day, ≥ 2.4 μg/day
Comments: The p value for linear trend was calculated by using the median of each quintile category as a continuous variable in the Cox models.

Other predictors/outcomes reported:
Follow-up duration (if applicable): | An average of 12.7 years in men and 17.3 years in women
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): A | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
RR of PD | Controlling for age, smoking, alcohol consumption, caffeine intake and lactose intake, there was no significant associations found between the baseline intake of folate, vitamin B6, or vitamin B12 in the Health Professionals Follow-up study (1986-2000) and the Nurse's Health Study (1980-1998) and multivariate relative risk of Parkinson's disease: all RRs in each quintile were not statistically different from 1.0 and the p values for the trend of RRs across quintiles for all vitamin examined were not significant.
| Individuals at either the low end (≤200 μg/day) or the high end (>1000 μg/day) of folate intake had a Parkinson's disease risk similar to the risk of those with normal folate intake, controlling for age, smoking, alcohol consumption, caffeine intake and lactose intake.
| Supplemental intake of folate, vitamin B6, or vitamin B12 was also not related to the risk of Parkinson's diseases. Compared with nonusers, individuals whose supplemental folate intake was more than 400 μg/day had a pooled RR of 1.0 (95%CI: 0.8, 1.2)

Note: Detail RR data by quintiles or by supplemental intake categories were showed in tables.

Correlation / FFQ

Author, Year: Deijen, 2003 | Ref ID: 765 | Vitamins: B1, B2, B6
Objective: To elucidate the relation between nutritional intake and daily functioning in psycho-geriatric elderly people

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS & Longitudinal | Age: | 83.0±7.0 SD | 110 psycho-geriatric residents of a nursing home | Psychiatric history, need of terminal care, suffering from cancer, rheumatoid arthritis, insulin dependent diabetes, serious overweight (BMI > 30 kg/m2), having a fiber-poor diet or a diet that can not be combined with food supplementation; younger than 65 years. | AD: | ND
| Non-Comparative | %Male: | 13% (12/90) | | The data from 20 subjects were excluded from evaluation due to incomplete data or failure to complete the total investigation period.
| Prospective | Race: | ND | | | PD: | ND
Country: | Netherlands | BMI: | 24.9±4.0 | | | VascDz: | ND
Setting: | Nursing home | | | | | Other:
Funding: Numico Research B.V.
Comments: During the study 60% of the dropouts became ill against 34% of the subjects who completed the study. In addition, within the group of dropouts, the percentage of males was higher than that of the study group (30% and 13% respectively)

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest
| | | | N enrolled: | 110 | 110
Thiamin intake (?) | A combination of a 3-day record and weighing-back methods at baseline, week 8, 16 and 24 (Nurses recorded). | Zorg Index Geriatrie (ZIG)- scales | The ZIG-scale consists of the ZIG-A scale (cognitive functioning), ZIG-B scale (physical functioning) and the ZIG-C scale (social functioning). The ranges of the ZIG-scales are from 6 to 24. The nursing-home caregiver(s) assessed subject's ZIG-scales. | N analyzed: | 90 | 90
Riboflavin intake (?) | | | | Drop-outs (%): | 18% | 18%
Vitamin B6 intake (mg)
Comments: | For the purpose of this review, only ZIG-A scale (cognitive functioning) is the outcome of interest.
| In correlation analyses, nutrition parameters were averaged for each subject across the 12 assessments: 3 across 1 week, 4 across 24 weeks. To determine possible relationships between the various nutrient s and ZIG-scores, partial correlations, controlling for BMI were computed. All bivariate correlations were computed by two-tailed tests.
| In longitudinal analyses, repeated measures analyses on the 4 data point (week 0, 8, 16 and 24) of the ZIG-scores and nutrient intakes were used.

Other predictors/outcomes reported: | Age; weight; BMI; energy, vitamin A, niacin, vitamin C intakes
Follow-up duration (if applicable): | 6 months
Reasons for drop out (if applicable): | Incomplete data or failure to complete the total investigation period. During the study 60% of the dropouts became ill against 34% of the subjects who completed the study.
Limitations: | Subjects were recruited from a nursing home (limited applicability).
| Dropouts had worse health status than the completers.
| If the outcome assessors (nursing-home caregivers) and the exposure assessors (nurses) were the same, a dependent misclassification bias would occur.
| The results clearly showed that subjects with high vitamin and energy intake were younger than those with a lower intake. However, the correlation analyses only controlled for BMI not age.
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text)
ZIG-A (cognitive) scale | Longitudinal analysis (repeated measurements analyses) were carried out with ZIG-scores as repeated measurement factor and 3 comparisons were separately made between low/high intake groups of vitamin B-6 as between subjects factor. The 2 experimental groups were formed based on high and low intakes of nutrients compared to the median intakes at baseline. There were no interactions between intake groups and week, indicating that the high and low intake groups had the same pattern of ZIG-scores across the 6-month experimental period.
| Disregarding the factor intake group, a significant increase in all ZIG scales was found across weeks (p<0.0005) indicating that a deterioration in cognitive, physical and social functioning takes place in the course of the 6-month study period.
| No significant increase of dietary vitamin B6 was seen across weeks.

Correlation of Predictors with Outcomes (cross-sectional studies)

Outcome | N | Mean intake of Thiamin | (unclear unit) | Mean intake of Riboflavin | (unclear unit) | Mean intake of Pyridoxine | (unclear unit)
| | r=* | p | r=* | p | r=* | p
ZIG-A (cognitive) scale, higher scores indicate worse cognitive function | 90 | 0.25 | 0.02 | 0.23 | 0.03 | ND | NS

* Partial correlations, controlling for BMI

Correlation / FFQ

Author, Year: Lee, 2000 | Ref ID: 1813 | Vitamins: B1; B2
Objective: To analyze the association between dietary intake and cognitive function of the Korean elderly

Study characteristics | | [underlined: Population] | | | Inclusion criteria | Exclusion criteria | Definitions
| | | Men | Women
Study design | XS | Age: | 72.3±6.5 SD | 69.6±6.0 | A random sample of elderly people who usually spend the daytime at the welfare center | Major cognitive function impairment. | AD: | ND
| Non-Comparative | %Male: | 47% (210/449)
| Prospective | Race: | Koran | | | | PD: | ND
Country: | Korea | BMI: | 23.3±3.4 | 24.5±4.1* | | | VascDz: | ND
Setting: | Community (primarily 2 elderly welfare centers) | WHR: | 0.91±0.05 | 0.88±0.05* | | | Cognitive function was classified according to MMSE-K scores: normal (≥24), inadequate (19–24), and poor (≤19)
| | | *p<0.01 b/w groups
Funding: | University
Comments: | Due to many significant differences in the anthropmetric measurements (e.g. BMI, height, weight, waist/hip ratio (WHR)), results for men and women should be discussed separately because all analyses were univariate.
| MMSE-K (Mini-Mental State Examination for Koreans) modified from Folstein et al's MMSE.

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
| | | | N enrolled: | 449 | 449
Thiamin intake (mg) | Single 24-hr recall | MMSE-K Status | Points ranged from 0 to 30. Normal (≥24), inadequate (19–24), and poor (≤19) | N analyzed: | 449 | 449
Riboflavin intake (mg) | Single 24-hr recall | | | Drop-outs (%): | N/A
Comments: 24 h diet recalls were done by a trained interviewer and with the use of food models. Nutrient intakes were calculated using the Computer Aided Nutritional (CAN) analysis software program developed by The Korean Nutrition Society. Incomplete and inconsistent data were excluded.

Other predictors/outcomes reported: | Age; education level; BMI; WHR; Food intakes; intakes of the major macro- and micro- nutrients
Follow-up duration
Reasons for drop out
Limitations: | Single 24-hr dietary recall cannot account for the day-to-day variations of nutrient/food intakes.
| Subjects may not represent the general elderly population in Korea.
| Age and education levels were found to be strongly related to cognitive function in both men and women, but most analyses of the association between food/nutrient intakes and MMSE-K status were not adjusted for these confounders. Elderly with higher education levels or younger age could give a more accurate 24-hr dietary recall, resulting in biases away from the null.
Quality (A/B/C): C | Applicability (1/2/3): 2

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | Dietary Intake of Thiamin | | (mg) | p | Dietary Intake of Riboflavin | | (mg) | p
| | Mean | SD | r=** | | Mean | SD | r=**
Men - Normal (≥24) | 136 | 0.95 | 0.35 | 0.083 | NS | 0.87 | 0.46 | 0.082 | NS
Inadequate (19–24) | 48 | 0.91 | 0.34 | | | 0.77 | 0.37
Poor (≤19) | 26 | 0.82 | 0.27 | | | 0.74 | 0.32
Women - Normal (≥24) | 86 | 0.91 | 0.39 | 0.125 | NS | 0.68 | 0.33 | 0.144 | <0.05
Inadequate (19–24) | 79 | 0.90 | 0.63 | | | 0.72 | 0.50
Poor (≤19) | 74 | 0.71* | 0.35 | | | 0.50* | 0.32

* values are significantly lower, p<0.05 by Duncan's multiple range test

** age controlled

Correlation / FFQ

Author, Year: Mizrahi, 2003 | Ref ID: 2188 | Vitamins: B6; folate
Objective: To examine the relationships of total plasma homocysteine levels (tHcy), dietary vitamin B6 and folate, ApoE genotype, cognitive performance, blood lipids and serum albumin in Alzheimer's disease (AD) patients and healthy controls

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Case-Control study | Age: | 74.1±7.9 SD | 74.6±6.9 | Cases: | For all participants: | AD: | Diagnosis of probable AD, fulfilling NINCDS/ADRDA criteria
| Comparative | %Male: | 45.3 | 45.3 | Cases were recruited from a Research Registry at an Alzheimer Center. Cases were matched by gender, year of birth, and smoking status to a pool of 382 healthy controls using propensity scores. | Presence of pernicious anemia, renal impairment, hypothyroidism, carcinoma of the breast, ovary and pancreas, severe psoriasis, and drugs (folate antagonists: methotrexate, phenytoin and carbamazepine and B6 antagonists: theophylline, azarabine, oestrogen-containing oral medications) known to increase tHcy levels
| Retrospective | Race: | ND | ND
Country: | US | %Current smokers: | 4.7 | 6.3 | Controls:
Setting: | Registry | Education, years | 12.5±2.9 | 15.2±2.8* | Controls age 60 years or older were recruited from friends or neighbors of cases or members of the organizations to which cases belonged. | | PD: | ND
| | MMSE score (maximum 30) | 17.7±6.8 | 28.8±1.1* | | | VascDz: | ND
| | %ApoE genotype, with 1 or 2 epsilon 4 | 61.7 | 14.3* | | | Other:
| | *p<=0.001 between groups
Funding: Non-profit organizations; NIH
Comments: Matched pairs analysis was only performed for the relationship between tHcy levels and the odds ratio for AD, which was not directly of interest to our report. The relationships between B6 or folate intakes and AD were done using unmatched analysis (two-sample t-tests), which doses not adjust for the necessary covariates.

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
| | | | N enrolled: | 446 | 64 | 382
Vit. B6 intake (mg/1000Kcal) | FFQ adapted from the Block Health Habits and History Questionnaire (HHHQ). Medium-sized portion is assumed for every food. Nutrient analyses of dietary consumption used folate values in foods before the US FDA made folate enrichment mandatory in January 1998. | AD patients vs. healthy controls | Two-sample t-tests for detecting differences between the 2 groups at 3 age periods: 20–39 years, 40–59 years, and 60+. | N analyzed: | 128 | 64 | 64
Folate intake (mg/1000Kcal) | | | Spearman correlation was used for correlations between tHcy levels and dietary Vit B6 and folate being consumed in the 3 age periods between AD patients or controls separately. | Drop-outs (%): | N/A | Control dropouts were due to matching | 83%
tHcy (μmol/L) | Samples were run on the Abbot Imx Platform, which is a fluorescence polarization immunoassay
Comments: Missing data on dietary intake for some of the participates resulted in slightly different sample sizes for the various time periods.

Other predictors/outcomes reported: | ApoE genotype; triglycerides; cholesterol; LDL
Follow-up duration
Reasons for drop out
Limitations: | FFQ is subject to recall biases and not a good method to assess absolute amount of dietary intakes. Controls might have more accurate recalls than the cases, because proxy or surrogate respondents were used to estimate cases' intake during 3 age periods (20–39 years, 40–59 years, and 60+ years)!
| Two-sample t-tests were used to compare the mean levels of dietary folate and vitamin B6 for AD patients and controls at 3 age periods: 20–39 years, 40–59 years, and 60+. This analysis dosen't adjust for the necessary covariates.
Quality (A/B/C): C | Applicability (1/2/3): 3

Outcome(s): | Results (Text)
AD patients vs. healthy controls | No statistically significant correlations were found between tHcy levels and dietary vitamin B6 and folate being consumed in the 3 age periods between AD patients or controls (Spearman correlation; p>0.05)
| AD patients had lower mean dietary vitamin B6 intake than controls in the 60+ years age period (p=0.05), but no differences in their 20–39 years (p=0.58) and 40–59 years age periods (p=0.61).
| AD patients had lower mean dietary folate intake than controls in the 60+ years age period (p=0.01), but no differences in their 20–39 years (p=0.6) and 40–59 years age periods (p=0.14).
| Note: Data for the dietary B6 and folate intakes were reported in figures.

Correlation / FFQ

Author, Year: Renvall, 1989 | Ref ID: 2686 | Vitamins: B1, B2, Folate, B12
Objective: To test the hypotheses that dietary intake and biochemical values of vitamin B12, folate, thiamine and energy would be lower in senile dementia of the Alzheimer's type (SDAT) patients than in elderly patients with normal cognition.

Study characteristics | | Population | | | Controls | | Inclusion criteria | Exclusion criteria | Definitions
| | | ♂ | ♀ | ♂ | ♀
Study design | XS | Age: | 75.4 | 77.9 | 71.1 | 71.4 | Cases: | For all participants: | AD: | ND
| Comparative | %Male: | 32%(7/22) | | 38%(13/41) | | Program participants who had a diagnosis of senile dementia of the Alzheimer's type (SDAT) | Subjects who did not complete the 3-day dietary record (n=6).
| Prospective | Race: | ND | | ND | | | Not all biochemical values were obtained from the subjects completing the dietary record. Information for each parameter is presented only for those subjects from whom both dietary and biochemical data were available. | PD: | ND
Country: | US | %Multi-Vit users: | 50% | 48% | 53% | 42% | Controls: | | VascDz: | ND
Setting: | Outpatient geriatric assessment program | | | | | | Elderly people (program participants) who were at least 60 years of age and free from acute illness or recent hospitalization. | | SDAT: | Diagnosis was determined by consensus of the medical team composed of internists, psychiatrists, and neurologists
Funding: NIH
Comments: | There was also a retrospective study (serum vitamin status only). Only the prospective study is reviewed here.
| SDAT patients (or population of interest) were significantly older than normal subjects.
| Biochemical values, age, MMSE scores and living situation did not differ between the excluded and included subjects. Mean body weight of the excluded subjects was significantly (p<0.006) lower than that of the participants.

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest | Control
| | | | N enrolled: | 69 | ND | ND
Thiamin intake (mg/day) (n=48) | Subjects or their caregivers were given oral and written instructions in keeping written 3-day food consumption records. The records were analyzed by computer program (Ohio State University) and missing values were added from atandard handbooks of food composition. Multivitamin supplements were taken sporadically by many of the subjects; therefore, values from supplements were not added to those of the diets. | SDAT vs. normal subjects | ANOVAR followed by Bonferroni tests, when appropriate, was used to measure differences among means for dietary and biochemical parameters. For this analysis, subjects were grouped by 1) cognition; 2) sex and cognition; or 3) supplement use and cognition | N analyzed: | <63 | <22 | <41
Riboflavin intake (mg/day) (n=51) | | | | Drop-outs (%): | >8.7%
Folate intake (μg/day) (n=37)
Vitamin B12 intake (μg/day) (n=43)
Blood thiamin level | Activity of RBC transketolase assay
Riboflavin ratio | The riboflavin content of casual urine samples was measured fluorometrically and corrected by creatinine concentration.
Comments: Dropout rates were larger than 8.7% because only subjects who had both dietary and biochemical data were analyzed.

Other predictors/outcomes reported: | Protein, energy, and iron intakes; RBC folate and serum vitamin B12; serum protein; serum albumin; hematocrit; hemoglobin
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Only subjects who had both dietary and biochemical data were analyzed. Dropout rate for some measures were as high as 41%.
| 3-day dietary records by subjects or their caregivers. No description which days in a week.
| The self-reported dietary intake and the biochemical values (blood markers) were weekly correlated. Correlation coefficients (data not shown) between the measures of nutritional status were higher in normal subjects than in SDAT subject. This indicates SDAT subjects had poorer dietary recalls. This confounding factor was not adjusted for in the analyses.
Quality (A/B/C): C | Applicability (1/2/3): 2

Correlation of Predictors with Outcomes (cross-sectional studies)

| SDAT subjects | Normal Subjects
Dietary values | Mean±SD [95%CI] | Mean±SD [95%CI]
Thiamin, mg/day (n=48, p<0.54) | 1.4±0.8 (n=15) [0.9–1.8] | 1.2±0.4 (n=33) [1.1–1.4]
Riboflavin, mg/day (n=51, p<0.66) | 1.6±0.6 (n=14) [1.3–1.9] | 1.5±0.6 (n=37) [1.3–1.7]
Folate, μg/day (n=37, p<0.54) | 169±74 (n=27?) [140–198] | 186±71 (n=10) [135–236]
Vitamin B12, μg/day (n=43, p<0.31) | 2.3±1.8 (n=21?) [1.5–3.1] | 2.9±2.3(n=22) [2.0–4.0]
Biochemical values | Mean±SD [95%CI] | Mean±SD [95%CI]
Thiamin
ETKAS, IU/ml/hr (n=48, p<0.49) | 4.3±1.6 (n=15) [3.4–5.2] | 3.9±1.6 (n=33) [3.3–4.5]
ETKAPH, IU/min/g hemoglobin (n=51, p<0.055) | 1.5±0.5 (n=14) [1.3–1.8] | 1.89±0.4 (n=28) [1.7–2.0]
Riboflavin ratio (n=51, p<0.44) | 1.9±1.9 (n=14) [0.8–3.0] | 3.1±5.9 (n=37) [1.1–5.1]

? Questionable values perhaps due to reporting errors

| [underlined: Supplement Users] | | [underlined: Supplement Nonusers]
| SDAT | Normal | SDAT | Normal
Biochemical values | Mean±SD | Mean±SD | Mean±SD | Mean±SD
Thiamin
ETKAS, IU/ml/hr (n=48, p<0.48) | 4.6±2.0 (n=7) | 3.8±1.7 (n=18) | 3.9±1.2 (n=8) | 4.0±1.5 (n=15)
ETKAPH, IU/min/g hemoglobin (n=51, p<0.03) | 1.7±0.3 (n=6) | 1.9±0.4* (n=15) | 1.4±0.6* (n=8) | 1.7±0.3 (n=13)
Riboflavin ratio (n=51, p<0.01) | 2.7±2.1 (n=8) | 4.7±7.6 (n=21) | 0.8±0.6 (n=6) | 1.0±0.6 (n=16)

* Significantly different means by Bonferroni correction: p<0.01

Correlation / FFQ

Author, Year: Requejo, 2003 | Ref ID: 2687 | Vitamins: B1, B2, B6, Folate; B12
Objective: To study the importance of nutrition in the maintenance of cognitive function in a group of elderly people.

Study characteristics | | Population | | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS | Age: | ≥ 65 | Noninstitutionalized elderly people (≥ 65 y) who spent part of their time at day centers | Any disease that might affect the food intake (neoplasms, liver or kidney disease, diabetes, etc), took medications that might influence the appetite, trying to gain or lose weight; manifest cognitive decline (MMSE<24) | AD: | ND
| Non-Comparative | %Male: | ND
| Prospective | Race: | ND | | | PD: | ND
Country: | Spain | Other: | | | | VascDz: | ND
Setting: | Community | | | | | Other:
Funding: ND
Comments:

Predictor(s): (eg, B vit level) | | Outcome(s): | Definition: | | Total | Population of interest
| | | | N enrolled: | 168 | 168
Thiamin intake (mg/day) | Precise individual weighing of food was performed for 5 days in order to monitor the food consumed at the midday meal, the only meal the subjects took at the centers. A 7-day food record was also kept, in which subjects noted all the foods they consumed. The energy and nutrient contents of the foods and drinks consumed were determined using the Institution of Nutrition's Food Composition Tables (Instituto de Nutricion, 1994) | Cognitive capacity | Folstein's MMSE was used. Points are awarded between 0 and 35, with 28 or more considered as normal. | N analyzed: | 168 | 168
Riboflavin intake (mg/day) | | | | Drop-outs (%): | N/A
Pyridoxine intake (mg/day)
Folate intake (μg/day)
Vitamin B12 (μg/day)
Comments: Since the test results get worse with advancing age (r=-0.2730, p<0.001), subjects were also grouped with respect to this parameter (either above or below the 75^th^ percentile (74.8 y]). The chi-square test was used to confirm the homogeneity of gender distribution between these groups.

Other predictors/outcomes reported: | Age; food consumption; other major macro- and micro- nutrients
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations: | Subjects may not represent general elderly people in Spain
Quality (A/B/C): B | Applicability (1/2/3): 2

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N=168 | Dietary Intake of Thiamin (mg/day) | | p | Dietary Intake of Riboflavin (mg/day) | | p
| | Mean | SD | | Mean | SD
MMSE ≥ 28 | | | | <0.1*
Age < 75^th^ percentile | ND | 1.12 ^a^ | 0.34 | | 1.43 ^a^ | 0.40 | <0.05**
Age ≥ 75^th^ percentile | ND | 1.12 ^a^ | 0.44 | | 1.52 ^b^ | 0.43
MMSE < 28
Age < 75^th^ percentile | ND | 1.05 ^b^ | 0.29 | | 1.39 ^a^ | 0.35 | <0.05**
Age ≥ 75^th^ percentile | ND | 0.96 ^b^ | 0.23 | | 1.46 ^b^ | 0.38

Difference in the subscripts indicates statistical significant differences between the groups.

* Differences obtained with respect to MMSE score

** Differences obtained with respect to age

Description of (Sub-) Groups | N=168 | Dietary Intake of Pyridoxine (mg/day) | | p | Dietary Intake of Folates (μg /day) | | p
| | Mean | SD | | Mean | SD
MMSE ≥ 28 | | | | | | | <0.05*
Age < 75^th^ percentile | ND | 1.40 | 0.39 | NS | 202.0 ^a^ | 73.7
Age ≥ 75^th^ percentile | ND | 1.36 | 0.48 | | 222.9 ^a^ | 113.8
MMSE < 28
Age < 75^th^ percentile | ND | 1.39 | 0.32 | NS | 182.9 ^b^ | 60.5
Age ≥ 75^th^ percentile | ND | 1.40 | 0.31 | | 180.5 ^b^ | 64.3

Difference in the subscripts indicates statistical significant differences between the groups.

* Differences obtained with respect to MMSE score

Description of (Sub-) Groups | N=168 | Dietary Intake of Vitamin B12 (μg /day) | | p
| | Mean | SD
MMSE ≥ 28
Age < 75^th^ percentile | ND | 7.3 | 7.9 | NS
Age ≥ 75^th^ percentile | ND | 7.3 | 5.4
MMSE < 28
Age < 75^th^ percentile | ND | 5.9 | 5.6 | NS
Age ≥ 75^th^ percentile | ND | 7.4 | 8.0

## Berry Evidence Tables - Animal / In Vitro Studies

Author, Year | Saija, 1990
Central hypothesis/Stated Purposes of Study | Myrtillinum (a purified Bilberry extract containing 15 anthocyanins) has capacity to affect T3 transport into brain in euthyroid rats
Hypothesis diagram | Myrtillinum administration → changes in T3 transport into brain
Experimental diets or reagents | Myrtillinum (a purified Bilberry extract containing 15 anthocyanins) was injected intraperitoneally at the dose of 200 mg/Kg/day for 3 consecutive days.
Control diets or reagents | Vehicle (26% ethanol/water, v/v; volume of injection: 0.2 ml/100 g body weight) injections
Study characteristics | Country: Italy
| Funding source: ND
Gap in Knowledge | Known: Flavonoids have been demonstrated to be potent non-toxic iodothyonine deiodinase inhibitors in microsomal membranes and in intact rat hepatocytes; they are specific high-affinity competitors for L-thyroxine (T4) binding to human T4-binding prealbumin, and very poor inhibitors of 3,3′,5-triiodothyronine (T3) binding to the nuclear T3 receptors.
| Unknown: The effects of myrtillinum (a purified Bliberry extract) on T3 transport into brain
Experimental model | Brain of adult Sprague-Dawley rats (330–350 g body weight)
Study design | 24-hr after the last injection, both vehicle- and myrtillinum-injected rats were decapitated 15 sec after anesthesia and the brain removed; tissue specimens were dissected from the ipsolateral hemisphere.
Final sample size | No Data
Duration | 3 days
Measurements / Endpoints / Outcomes of interest | Percent brain uptake index of [^125^I]L-T3, analyzed by different brain fractions
Other outcomes reported
Results | Administration of myrtillinum induced a significant increase in T3 transport into frontal cortex, temporoparietal cortex, occipital cortexs, hippocampus, thalamus, hypothalamua and brain-stem (p<0.05). No significant change in T3 transport into striatum, inferior colliculus, and cerebellum.
Authors' Conclusions | Administration of myrtillinum induced a significant and widespread increase in T3 transport into brain.
Quality | B
Limitations / Comments | There was no expected direction of effects of myrtillinum on T3 transport into brain to begin with. The primary goal of this short study (only 2 pages) is to find out what will happen and generate some possible hypotheses. Not sure how relevant of the findings from this study to the neurodegenerative diseases.
| No data on the numbers of animals

Author, Year | Wang, 1996
Central hypothesis/Stated Purposes of Study | To show the differential inhibition of eukaryote protein kinases by condensed tannins prepared from a variety of plant sources, including gooseberry (Ribes grossularia fruit), red currant (Ribes rubrum fruit), blueberry(Vaccinium corymbosum fruit) ... etc.
Hypothesis diagram | Condensed tannins isolated from fresh fruits → inhibit PKC activities
Experimental diets or reagents | Condensed tannins (polymers consisting of flavan monomers, such as procyanidin and prodelphinidin units) isolated from fresh fruits (inhibitors), including gooseberry (exp#6), red currant (exp#17), and blueberry (exp#18). The composition and relative stereochemistry proportions of these tannins are as below:
| Tannin preparation | cis/trans | Procyanidin/prodelphinidin | M_N_
| Gooseberry tannin | 63/37 | 77/23 | 2700
| Red currant tannin | 24/76 | 78/22 | 2700
| Blueberry tannin | 100/0 | 96/4 | 3500
Control diets or reagents | N/A
Study characteristics | Country: New Zealand
| Funding source: Australian Research Council; University fund
Gap in Knowledge | Known: Previous study showed that a range of condensed tannin deriving from the cladodes ofPhyllocadus trichomanoides, the barkof Pseudotsuga menziesii and the heartwood ofAcacia melanoxylon are potent inhibitors of PKC and CDPK while being in general relatively poorer inhibitors of cAK.
| Unknown:
Experimental model | Rat brain PKC (specific activity 0.6 μmol min^-1^ mg protein^-1^ with 3.5μM EGFRP as substrate) was extensively purified and assayed in standard assay conditions. Inhibitor IC_50_ values (concns for 50% inhibition of particular protein kinases in the standard assay conditions) were determined from interpolation of plots of protein kinase activity versus inhibitor concn. Control protein kinase activity (no added inhibitor) was routinely determined 6 times and assays with inhibitor included were determined in duplicate. All assay results were corrected by subtraction of blank values from assays conducted in the absence of added protein kinase.
Study design | In vitro
Final sample size | N/A
Duration | N/A
Measurements / Endpoints / Outcomes of interest | Inhibitor IC_50_ values (μM) of rat brain protein kinase C (PKC)
Other outcomes reported | The composition and relative stereochemistry proportions of condensed tannin preparations
| Inhibitor IC_50_ values (μM) of chicken gizzard myosin light chain kinase (MLCK), wheat embryo CDPK, and rat liver cyclic AMPdependent protein kinase catalytic subunit (cAK)
Results | Tannin preparations from gooseberry (exp#6), red currant (exp#17), and blueberry (exp#18) have similar effectiveness as inhibitors of rat brain PKC with IC_50_ values (0.7, 0.6, and 0.5 μM respectively) as each other and compared to other plant tannins.
Authors' Conclusions | Tannin preparations from gooseberry, red currant, and blueberry have similar effectiveness as inhibitors of rat brain PKC
Quality | A
Limitations / Comments | Not sure how relevant of the findings from this study to the neurodegenerative diseases.

Author, Year | Joseph, 1998A [UI#9928436] and Bickford, 1999*
Central hypothesis/Stated Purposes of Study | Diets supplemented with vitamin E, strawberry extracts, spinach, or blueberry extracts may help animals resistant to the deleterious effects of 48 h of 100% oxygen exposure (normobaric hyperoxia) on several neuronal parameters
Hypothesis diagram | Dietary antioxidants ↓
| Oxidative stress (OS) due to hyperoxia → X → reduce β -adrenergic receptor function in the cerebellum
Experimental diets or reagents | Strawberry diet: control diet supplemented with strawberry extracts (9.4 g/kg dried aqueous extract)
| Blueberry diet: control diet supplemented with blueberry extracts (10 g/kg dried aqueous extract)
Control diets or reagents | AIN-93
Study characteristics | Country: US
| Funding source: No data
Gap in Knowledge | Known: Research has indicated that animals maintained on diets containing fruits or vegetables that are high in antioxidant activity are more resistant to the deleterious effects of 48 h of 100% oxygen exposure on several neuronal parameters that also show declines in aging.
| Unknown: The effects of diets supplemented with vitamin E, strawberry extracts, spinach, or blueberry extracts on several neuronal parameters. [Note: for the purpose of this review, only diets supplemented with strawberry extracts, blueberry extracts, and control diet are of interest]
Experimental model | 6- to 8- month-old F344 rats
Study design | Rats were fed the experiment or control diets for 8 weeks prior to 48 h of normobaric hyperoxia.
Final sample size | No data
Duration | 8 weeks
Measurements / Endpoints / Outcomes of interest | Dopamine release in striatal
| β -adrenergic receptor function in the cerebellum: isoproterenol modulation of GABA cerebellar Purkinje neurons (% cells modulating).
Other outcomes reported
Results | Data for the results of dopamine release in striatal is not shown.
| Rats fed diets supplemented with strawberry extracts were protected from the damaging effects of hyperoxia as shown in the β -adrenergic receptor function of the cerebellar purkinje neurons (p>0.01).
Authors' Conclusions | Diets supplemented with strawberry extracts and blueberry extracts were both effective in striatal oxotremorine enhancement of dopamine release (data not shown) and β -adrenergic receptor function in the cerebellum.
Quality | C
Limitations / Comments | Joseph, 1998A is a review article with a paragraph reporting the preliminary data. Later, the data was published in one section of results in Bickford, 1999
| The amount of added food extracts at 1.36 mmol Trolox equivalents as determined by the ORAC assay.
| Limited data presented in the articles and need to cross reference for more complete reporting. Unclear methods.

* This is a review article with some primary data in “3.4. Effects of hyperoxia on cerebellar physiology: nutritional interventions”

Author, Year | Joseph, 1998B [UI#9742171]
Central hypothesis/Stated Purposes of Study | Role of long term feeding dietary phytochemicals and antioxidants to ameliorate or prevent age related decline in CNS functions and neurodegenerative diseases
Hypothesis diagram | Oxidative stress may be a factor in neuronal loss in aging and enhanced loss in age-related neurodegenerative diseases; hence reduction in OS with exogenous antioxidant may help
Experimental diets or reagents | Strawberry 9.5 g/kg diet (also spinach and Vit E groups)
Control diets or reagents | Modified AIN-93 diet (described in table 1)
Study characteristics | Country: US
| Funding source: Government
Gap in Knowledge | Known: OS may play an etiological role in age related neurodegeneration and there is an age related decrease in the endogenous antioxidants. Diets rich in fruits and vegetables have high antioxidants
| Unknown: Role of exogenous antioxidants to prevent loss of Ca homeostasis and loss of cognitive performance
Experimental model | Male Fischer rats, from age 6–15 months
Study design | Randomized controlled trial
Final sample size | 80 in total
Duration | 8 months
Measurements / Endpoints / Outcomes of interest | DA release from striatal slices,^45^Ca recovery, cognitive testing, oxidative stress, GTPase activity
Other outcomes reported | Electrophysiology, weights and food intakes
Results | DA release: (assumed 8 animals per group) Significant oxotremorine-enhanced K+ evoked striatal dopamine release (K+ ERDA) from animals maintained on strawberry diet compared to control diet (p<0.034).
| ^45^Ca recovery was significant greater in strawberry group exposed to H_2_O_2_ treatment but not in control diet group exposed to H_2_O_2_ .(p<0.02) In the control diet^45^Ca recovery was significantly decreased in the H_2_O_2_ exposed than non exposed controls.(p<0.001)
| Cognitive testing: Morris Water maze trial 1 showed a significant effect for strawberry group for latency (p<0.05) and distance (p<0.01). No difference between strawberry and control on working memory trial 2 performance
| Oxidative stress: In the cerebellar tissue strawberry group showed increased native protection compared to the control group (p<0.0001).
| GTPase activity: Age-induced decrements in carbachol stimulated GTPase activity were significantly less with strawberry than control (p<0.0001).
Authors' Conclusions | Phytochemicals present in antioxidant rich foods such as spinach may be beneficial in retarding functional and age-related CNS and cognitive behavioral deficits
Quality | A
Limitations / Comments | Pre trial data on the animals unknown

Author, Year | Bickford, 1999*
Central hypothesis/Stated Purposes of Study | If oxidative stress is important for the development of age-related declines in CNS function, then treatment of rats with antioxidants should prevent some of the neurodegenerative alterations observed during the aging process.
Hypothesis diagram | Diets supplemented with antioxidants → delay the onset of age-induced alterations in cerebellar physiology and delay motor learning declines
Experimental diets or reagents | Not reported, but presumable same as previous study, as below:
| Strawberry diet: control diet supplemented with strawberry extracts (9.4 g/kg dried aqueous extract)
| Blueberry diet: control diet supplemented with blueberry extracts (10 g/kg dried aqueous extract)
Control diets or reagents | Not reported, but presumable same as previous study: AIN-93
Study characteristics | Country: US
| Funding source: No data
Gap in Knowledge | Known: The noradrenergic input to cerebelaar Purkinje neurons inhibits spontaneous discharge and thus has been previously characterized as a 'modulatoray" input. It has been shown that NE, applied iontophoretically or via activation of the locus coeruleus, will potentiate GABA-induced inhibitions of cerebellar Purkinje neurons via the β-adrenergic receptor. This effect of NE is altered in aged rats such only 30% of cells in aged rats demonstrate this effect whereas 70%–80% of neurons recorded in young animals will show an increase in the response to GABA during application of isoproterenol (ISO). Depletion of cerebellar NE or blockade of β-adrenergic receptors impairs the ability of rats to improve performance on a runway task where the rats must learn to walk on varying patterns of pegs that protrude from the runway walls.
| Unknown:
Experimental model | 6-month-old F344 rats
Study design | Rat fed diets supplemented w/ (vitamin E), strawberry extracts, (spinach), or blueberry extracts, compared to those fed control diet.
Final sample size | No data
Duration | Long-term feeding: 9 months
| Short-term feeding: 2 months
Measurements / Endpoints / Outcomes of interest | Long-term feeding:
| β -adrenergic receptor function in the cerebellum: % neurons
| Short-term feeding:
| Rod walking motor learning task: Data collection begins when rat has performed 2 successful traverses of the entire length of the uncovered rods in less than 1 min. Daily performance calculated by determining the running time for 20 successive trials/day. Sessions are conducted for 5 days during this phase of training. (This measure was done for short-term feeding study only)
| ISO potentiation of GABA
Other outcomes reported
Results | Long-term feeding: Strawberry supplemented diet improved β -adrenergic receptor function in the aged rats when compared to control diet fed animals of the same age (p<0.01)
| Short-term feeding: Data not shown
Authors' Conclusions | Long-term feeding: Long-term feeding of diets high in antioxidant potential is capable of delaying the onset of age-induced alterations in cerebellar physiology.
| Short-term feeding: Diets supplemented with strawberry extracts and bluebecrry extracts for 2 months reversed the age-related decline in both ISO potentiation of GABA and in motor learning.
Quality | C
Limitations / Comments | Limited data presented in the articles and need to cross reference for more complete reporting; Unclear methods

* This is a review article with some primary data in “3.5. Effects of nutritional intervention on cerebellar physiology”

Author, year | Joseph, 1999
Central hypothesis/Stated Purposes of Study | To examine whether dietary supplementation with spinach, strawberry, or blueberry extracts would be effective in reversing age-related deficits in neuronal and behavioral function in aged (19 months) rats.
Hypothesis diagram | Increase in dietary antioxidant levels → decrease OS → reversing age-related deficits
Experimental diets or reagents | 1.48% strawberry extract;(0.91% spinach extract); 1.86% blueberry extract (w/v) added to a control diet of modified AIN-93 diet.
Control diets or reagents | Modified AIN-93
Study characteristics | Country: US
| Funding source: supported by the US Department of Agriculture
Gap in Knowledge | Known:
| Unknown:
Experimental model | Fischer 344 rats had been shown to exhibit decrements by 15 months of age.
Study design | 19 month old Fischer 344 rats; 4 groups; each group was fed a different diet for 8 weeks; then was given the experiments.
Final sample size | Control 10 rats; strawberry 10; blueberry 10
Duration | 8 weeks
Measurements / Endpoints / Outcomes of interest | A battery of age-sensitive tests of psychomotor behavior was administered in a randomized order. Each test was performed once, separated by no less than a 1 hr break between tasks. The tests included rod walking; wire suspension; plank walking; inclined screen and accelerating rotarod.
| Cognitive testing used the working memory version of the Morris water maze. It was performed daily for 4 consecutive days, with a morning and an afternoon session, two trials (trial 1 and trial 2) each session, with a 10 min intertrial interval.
| Dopamine release
| GTPase activity: all striatal slices
| Ca^2+^ recovery were examined in the striatal synaptosomes
| Analyses of oxidative stress
Other outcomes reported | Vitamin E analyses
Results | Psychomotor behavior:
| Significant effects of diet on rod walking (p<0.05) and the accelerating rotarod (<0.05).
| For the rod walk, latency to fall was significantly longer in the blueberry groups compared to control (p<0.01) and strawberry (p<0.01) compared to control
| For the accelerating rotarod, latency to fall was longer in the blueberry group compared to the strawberry (p<0.05) group, and tended to be higher than the control group (p=0.06).
| There was no effect of diet group on wire suspension, inclined screen, or any measure of plank walking.
| Cognitive testing:
| ANOVA showed no effects of diet for either trial 1 or trial 2 performance on latency, distance, or speed.
| However, when separate t tests were performed between the two trial latencies for each diet, positive effects of diet supplementation were observed.
| For latency to find the platform on days 3 and 4, the strawberry (p<0.05), and blueberry (p<0.01) groups showed significant differences between trial 1 and trial 2, i.e. trial 2 latencies were significantly less than trial 1.
| This one-trial learning was not found in the control group.
| For distance swam to the platform on days 3 and 4, similar results were found, strawberry (p<0.05), blueberry (p<0.01) groups showed significant improvements between trial 1 and trial 2, with trial 2 distances significantly less than trial 1.
| No significant improvement was seen in the control group.
| Dopamine release:
| All striatal slices obtained from the animals in the various diet groups (6 animals per group) showed significantly greater oxotremorine-enhanced striatal dopamine release then that seen in those obtained from animals maintained on the control diet (control versus strawberry p<0.0001, control versus blueberry p<0.0001).
| Additional post hoc comparisons indicated that oxotremorine-enhanced dopamine release in the blueberry-fed group was greater than that seen in the strawberry-fed (p<0.0001) group.
| GTPase activity: Age-induced decrements in carbachol stimulated GTPase activity were significantly less with blueberry (p<0.0001) but not strawberry (p>0.05) than control.
| Oxidative stress: In the striatum, only the strawberry group (p<0.002) and blueberry (p<0.005) groups showed greater native OS protection than control group.
| Stawberry diet had greater^45^Ca recovery (p<0.001), whereas the blueberry diet had lower recovery (p<0.05), in non-H_2_O_2_-treatedsynaptosomes compared to the control diet. After treatment with 300 μM H_2_O_2_ only the blueberry group showed greater^45^Ca recovery (p<0.05) after treatment, i.e., a greater ability to extrude or sequester calcium after depolarization, than the control group. In fact, after exposure to H_2_O_2_ only the blueberry-fed diet group had no deficits in^45^Ca recovery.
Authors' Conclusions | Supplementation with the blueberry extract improved motor performance on 2 motor tests that rely on balance and coordination.
| These rats demonstrated one-trial learning, even with the 10 min retention interval.
Quality | A
Limitations / Comments | The amounts of strawberry and blueberry extracts added into the control diet were based on an equivalent ORAC activity so that each diet provided equivalent antioxidant activity.

Author, Year | Shukitt-Hale, 1999
Central hypothesis/Stated Purposes of Study | To determine the efficacy of dietary supplementation with antioxidants in reversing/restoring age-related declines in motor performance in mice
Hypothesis diagram
Experimental diets or reagents | Freeze-dried aqueous strawberry extract (1%)
Control diets or reagents | Modified AIN76 diet with 30 ppm Vit E
Study characteristics | Country: US
| Funding source: No data
Gap in Knowledge | Known: Oxidative stress (OS) is thought to be a contributing factor to the decrements in motor performance seen in aging. Antioxidant nutrients added to the diet are one defense strategy to prevent, intercept, or repair age-induced OS. Vitamin E, glutathione (GSH), melatonin, and strawberry extract have all been found to have antioxidant properties.
| Unknown:
Experimental model | Male C57BL.6NIA mice, 18 months of age before the dietary treatments.
Study design | Randomized control trial: weight matched mice were randomly assigned to 1 of 6 diet groups.
| An untreated group (n=11) of 4-month-old mice served as young, chow-fed, controls.
Final sample size | Weight-matched dataset:
| Control: 8 Strawberry: 10
Duration | 6 months
Measurements / Endpoints / Outcomes of interest | Behavioral testing: a battery of psychomotor behavioral tests was performed that consisted of complex movement tasks, which have been shown to deteriorate with age. The tests included: 1) Rod walking, 2) Wire suspension/wire hanging, 3) Plank walking; 4) Inclined screen
Other outcomes reported | Body weight
Results | For control rats only, several tests showed deficits from 4 to 18 months; however, no tests showed additional performance decrements from 18 to 24 months. Specifically, in the rod walking test and wire-hang test, ANOVA showed a significant age difference (p<0.01); post-hoc testing showed that latency to fall was longer for the young group than for the 18-month (p<0.01) or the 24-month group (p<0.01). Only data from the 4- and 24-month groups were comparable for the inclined screen, as both of these group were tested at the 85° angle (60° angle proved too easy for the mice as they all achieved max time regardless of age or diet), there was a significant age effect on the inclined screen (p<0.01), with the 24-month-old animals having a shorter latency to fall than the 4- month-group. There were no age differences for plank walk latency, distance, or turns.
| There was no significant difference in the any parameter (when analyzing the weight-matched dataset) between strawberry-fed and control animals.
Authors' Conclusions | Although some deficits were seen from 4 to 18 months, motor performance for the 18-month group on all measures was never different from the 24-month group.
Quality | A
Limitations / Comments | To control for the difference in body weight and prevent its influence on the behavioral tests, subsequent ANOVAs were run on a subset of the animals by discarding mice with a weight of greater or less than 1 standard deviation away from the mean weight of all the mice. A total of 32 mice were eliminated from the analyses.

Author, Year | Bickford, 2000
Central hypothesis/Stated Purposes of Study | Combinations of nutrients in foods with high antioxidant activity may reverse the age-related behavioral and neurochemical deficits in older rats. High antioxidant foods may improve cerebellar β-adrenergic receptor function, thus improving cerebellarmotor learning in older rats.
Hypothesis diagram | Combinations of nutrients in foods with high antioxidant activity → cerebellar β-adrenergic receptor function → motor learning
Experimental diets or reagents | Strawberry diet: control diet supplemented with strawberry extracts (14.8 g/kg dried aqueous extract)
| Blueberry diet: control diet supplemented with blueberry extracts (18.6 g/kg dried aqueous extract)
Control diets or reagents | Modified AIN-93 (Detailed composition listed in Table 1)
Study characteristics | Country: US
| Funding source: supported by the US Department of Agriculture, Veterans Administration Medical Research Service, and US Public Health Service
Gap in Knowledge | Known: Combinations of nutrients in foods with high antioxidant activity delay age-related behavioral and neurochemical deficits in young rats.
| Unknown: Whether high anti-oxidant diet at a later age would reverse the age-related deficits in behavior and β-adrenergic receptor function in the cerebellum.
Experimental model | Male Fischer (F344) rat, 18 months of age
Study design | Parallel comparative study
Final sample size | 30 (14 control, 8 blueberry, 8 strawberry)
Duration | 8 weeks, from age 18 to 20 months
Measurements / Endpoints / Outcomes of interest | Motor learning: Time to cross runway of variably placed rods. 1) Actual time (% of initial running time); 2) Decay constant (slope, rate of learning of the task).
| Extracellular electrophysiologic recordings of cerebellar Purkinje neurons for potentiation of GABAergic inhibition by the β- adrenergic ISO (post-mortem)
Other outcomes reported | Total glutathione levels in the cerebellum (post-mortem)
Results | Motor learning:
| 1 No significant difference in asymptote (percent of initial running time after 10–14 days) between blueberry or strawberry compared to control diets.; 2 Trend toward faster learning (steeper decay constant [slope], p=0.15) in blueberry diet rats compared to control (non-significant).
| (However, strawberry-fed rats were faster than controls at baseline, thus they did not have a steep learning curve.)
| Electrophysiologic recording: ISO potentiation of GABAergic inhibition in the cerebellum in observed in a significantly higher percentage of neurons recorded from the blueberry- (p<0.001) and strawberry-fed (p<0.05) groups as compared to control.
Authors' Conclusions | Diets high in antioxidants can improve performance on a motor learning task and reverse an age-induced decline in cerebellar β-adrenergic receptor function.
| The improvement in speed during the first few days for the strawberry and blueberry fed rats might be due to improved psychomotor performance as opposed to improved motor learning; however an effect on learning within the first training session would not be detected.
| Further experiments are required to investigate the effects of the various phytochemicals found in these foods.
Quality
Limitations / Comments | The amounts of strawberry and blueberry extracts added into the control diet were based on an equivalent ORAC activity so that each diet provided equivalent antioxidant activity.

Author, Year | Martin, 2000
Central hypothesis/Stated Purposes of Study | (1) to analyze the long-term (8 months) effect of low vitamin E in brain and other tissues; (2) to examine the brain's vitamin E distribution following dietary vitamin E treatment; (3) to determine if low vitamin E intake could affect vitamin C synthesis to compensate for the vitamin E deficit; and (4) to determine function and attenuate the deleterious effects associated with aging without affecting the concentrations of vitamins E and C
Hypothesis diagram | Antioxidants from fruits and vegetables → reduction of oxidative stress → prevention of neurodegenerative diseases
Experimental diets or reagents | Strawberry exact (9.5 g/kg diet), [spinach (6.4 g/kg diet), or vitamin E (with 500-mg all-rac-α-tocopheryl acetate/kg diet)] added tothe control diet
Control diets or reagents | Modified AIN-93
Study characteristics | Country: US
| Funding source: ND
Gap in Knowledge | Known: Age-related neurological deterioration is accompanied by a significant decrease of transmitter levels as well as activity of neurotransmitter-synthesizing enzymes.
| Unknown: Antioxidants may play in preventing oxidative damage and their application in the prevention of neurodegenerative diseases.
Experimental model | 6-month-old male Fischer 344 rats (Harlan Sprague Dawley, Indianapolis, IN) were used. When testing, all rats were at the age of 15 months.
Study design | Following a 12-day acclimatization period to the facility, the 6-month-old male Fischer 344 rats (were weight-matched and given 2 weeks on the control diet. They were then divided into 4 diet groups (control, strawberry extract, spinach extract and high vitamin E groups). [Note: for the purpose of this report, only control and strawberry extract groups are of interest.]
Final sample size | Ctrl | 20
| Strawberry | 20
Duration | 8 months
Measurements / Endpoints / Outcomes of interest | Dopamine release
Other outcomes reported | Weight and food intakes
| Vitamins E and C levels in brain (hippocampus, cerebellum, and striatum), plasma, in liver, and in heart
Results | Diets enriched with extracts of strawberry showed enhanced dopamine release from striatal slices following oxotremorine stimulation by 100% compared to control (p<0.05)
Authors' Conclusions | The observation that dopamine release induced by the diets containing strawberry was significantly enhanced compared to control diet is important, because brain tissues from control and experiment animals had very low vitamin E, compared to the high-vitamin-E group suggesting that other nutrients may be important for maintaining brain's function.
Quality | B
Limitations / Comments | No behavioral or cognitive function outcomes

Author, Year | Youdim, 2000
Central hypothesis/Stated Purposes of Study | Blueberry supplementation diet prevents the cognitive decline through decreasing the susceptibility to OS; and may have benefits in peripheral systems.
Hypothesis diagram | 1 BB supplementation diet → decrease susceptibility to OS, ?dopamine release → decrease cognitive decline; 2 BB supplementation diet → increase aminotransferase (AST) activity → benefits in peripheral tissue function
Experimental diets or reagents | Blueberry (BB) supplemented diets: 2% of the control diet was supplemented with either wild blueberry or tif-blue blueberry extract. Overall this was equivalent to the consumption of 4 g of BB (1 kg of whole BB yielded 110 g of BB extract, assuming that rats consumed approximately 20 g diet/day).
Control diets or reagents | Control diet specification was described in Table 1
Study characteristics | Country: US
| Funding source: ND
Gap in Knowledge | Known: Previous studies showed that rats maintained on diets enriched with strawberry or spinach extracts for 8 months exhibited less age-related deficits in neuronal signal transduction and cognitive behavior impairment.
| Unknown: If the beneficial effects can be observed when using a well-balanced chow diet that already contained sufficient levels of vitamin E, and which overall was more comparable with a normal balanced human diet.
Working model | 17-month Male Fisher 344 rats (Harlan Sprague Dawley, Indianapolis, IN)
Internal standard | 6-week run-in control chow diet
Study design | RCT of control, tif-blue blueberry (tif-BB) and wild blueberry (wild BB) diets. 15 rats per groups.
Final sample size | Control: 12 | tif-BB:13 | Wild-BB:14
Duration | 8 weeks
Measurements / Endpoints / Outcomes of interest | Age-sensitive tests of psychomotor behavior: 1) Rod walking, 2) Wire suspension, 3) Plank walking, 4) Inclined screen; 5) Accelerating rotarod
| Cognitive testing: Morris water maze, latency to find the platform, distance swam, and speed, were calculated separately for Trials 1 and 2. Performance was assessed over 4 days (2 sessions/day, 2 trials/session)
| Dopamine release
Other outcomes reported | Erythrocyte ghost membrane fluidity
| RBC susceptibility to OS insult: dichlorofluorescein (DCFH-DA) assay
| Flavonoid extraction from plasma
Results | Tests of psychomotor behavior:
| Tif-BB → latency to fall was significantly longer compared to on the inclined screen (p=0.06) and the large plank (p<0.05), but no significant difference in the accelerating rotarod testing.
| Wild-BB → latency to fall was significantly longer compared to control on the accelerating rotarod (p<0.05) and the large plank (p<0.05), but no significant difference in the inclined screen testing.
| Morris water maze:
| Tif-BB → significantly lower latency to find the platform on Trial 1 (p<0.05) but the latency was not different on Trial 2
| Wild-BB → no significant difference in the latency to find the platform on both Trial 1 and 2
| Dopamine release: Both Tif-BB (p<0.05) and Wild BB (p<0.05) supplemented animals showed significantly greater oxotremorine-enhanced striatal dopamine release than control animals, but they were not differ from each other.
Authors' Conclusions | Supplementation with the BB extract improved performance on motor tests, and enhanced striatal dopamine release.
| Tif-BB supplementation improved reference memory performance (Trial 1 only), but not wild-BB supplementation.
Quality | A
Limitations / Comments | The effects on improving memory performance were weak.

Author, year | Joseph, 2003
Central hypothesis/Stated Purposes of Study | Blueberry supplementation may be of benefit in reducing the symptomology of Alzheimer's disease (AD)
Hypothesis diagram | BB suppl → increase GTPase, decrease N-Sase, ?PKC; ?ERK → improve Y-maze performance; less Aβ deposition in the brain
Experimental diets or reagents | Blueberry (BB) supplemented diet: 2% of the control diet was supplemented with BB extract from 4 months through 12 months of age
Control diets or reagents | Control diet (modified NIH-31) specification was described in Table 1
Study characteristics | Country: US
| Funding source: ND
Gap in Knowledge | Known: 1) significant reductions in muscarinic receptor -G protein signaling as a function of AD and aging; 2) increase in neutral sphingomyeline-specific PLC (N-Sase) activity with age
| Unknown: other signaling parameter associated with aging, e.g. calcium-dependent protein kinase C (PKC), extracellular signal regulated kinase (ERK)
Experimental model | Mice transgenic for amyloid precursor protein (APP) and presenilin-1 (PS1) mutations. These mice are prone to fibrillar Aβ deposits in cerebral cortex and hippocampus early in the life-span with later changes in cognitive behavior
Study design | Transgenic vs. non-transgenic mice (CTR-N), both groups on either blueberry diet (BB) or control diet (Control)
Final sample size | Transgenic BB | 3 | CTR-N BB | 7
| Transgenic Control | 3 | CTR-N Control | 8
Duration | 12 months
Measurements / Endpoints / Outcomes of interest | Y-maze performance
| Fibrillar Aβ deposits in the brain
| Brain neutral sphingomyelin-specific phospholipase C (N-Sase) activity
| Brain low Km GTPase activity
| Brian calcium-dependent protein kinases (PKC) activity: protein kinase Cγ (PKCγ); phospho-protein kinase Cα
| Brian extracellular regulated signal kinases (ERK) activity
Other outcomes reported
Results | BB supplementation had a beneficial effect on Y-maze performance in transgenic mice, as demonstrated by higher percentages of alternation behavior [p<0.05]
| There is no significant difference I the Y-maze performance between the wild-type mice fed blueberry diet and those fed control diet.
| BB supplemented transgenic mice had no change on Aβ deposits in the brain
| BB supplementation significantly increased the low Km GTPase activity (p<0.05) in striatum but not in hippocampus or cortex in transgenic animals compared to the respective controls. No significant effects of BB supplementation was found in non-transgenic animals. Positive correlation between GTPas activity and Y-maze alternation in the striatum but not in the hippocampus or cortex
| BB supplementation significantly decreased N-Sase activity for both transgenic animals (p<0.01) and controls (p<0.01) in the striatum, hippocampus, and the cortex. Negative correlation between N-Sase activity and Y-maze alternation in the striatum but not in the hippocampus or cortex
| BB supplementation increased hippocampal ERK activity in the transgenic mice (p<0.001). Other brain regions were not examined. Correlation between hippocampal ERK activity and Y-maze alternation did not reach significance.
| The levels of PKCγ were unaffected by the transgenic condition or the diet (data not shown) in any of the brain regions examinedand the correlations between this parameter and Y-maze alternation were not significant.
| BB supplementation increased hippocampal phospho-PKCα activity in the transgenic mice (p< 0.05). No differences were seen in other brain areas among the various groups. Correlational analyses with Y-maze performance revealed a trend towardsignificance in the hippocampus (p=0.09)
Authors' Conclusions | BB suppl → increase GTPase (yes in striatum, p< 0.05), decrease N-Sase (yes in striatum and hippocampus, p< 0.01), PKC (no effect); ERK (increase in hippocampus, p< 0.01) → improve Y-maze performance (yes, p< 0.05); less Aβ deposition in the brain(no)
| Although BB supplementation did not affect Aβ deposits, the supplementation seemed to have prevented the deficits in Y-maze performance seen in the transgenic animals fed the control diets.
Quality | A
Limitations / Comments | Transgenic mice should have lower Y-maze performance, lower GTPase activity, higher N-Sase activity compared to CTR-N mice when feeding control diet (data were shown).
| Correlate the “intermediate markers” to the neurocognitive measures!

Author, Year | Casadesus, 2004
Central hypothesis/Stated Purposes of Study | To examine whether neurogenesis, growth factors, and mitogen-activated protein-kinase (MAPK), in combination or synergistically, were associated with improvements in hippocampally-dependent cognitive output in aged blueberry-supplemented rats
Hypothesis diagram | Blueberry supplementation → ? neurogenesis, ? growth factors ? MAPK → improve cognitive output
Experimental diets or reagents | Blueberry extract diet: 2% of the control diet was supplemented with blueberry extract. Overall this was equivalent to the consumption of 4 g of BB (1 kg of whole BB yielded 110 g of BB extract, assuming that rats consumed approximately 20 g diet/day).
Control diets or reagents | NIH-31 20g/kg
Study characteristics | Country: US
| Funding source: No data
Gap in Knowledge | Known: Dietary fruit and vegetable supplementation appear to forestall or reverse various age-related neuronal declines.
| Unknown: The mechanisms responsible for behavioral and neuronal changes seen during aging are not fully understood.
Experimental model | 19-month-old male F344 rats (Harlan Sprague-Dawley, Indianapolis, IN)
Study design | RCT
Final sample size | 10 in total (assumed 5 per group)
Duration | 8 weeks
Measurements / Endpoints / Outcomes of interest | Radial Arm Water Maze (RAWM) performances: rats were tested for 5 consecutive days. The order of entry into the maze arms was recorded so that the number of errors could be analyzed. The errors recorded were reference (long-term) memory errors (defined as entering an arm that disen't contain the platform) and working (short-term) memory errors (defined as the animal re-entering an already visited arm whether or not it contained the platform). Total memory errors refer to the addition of reference and working memory errors.
| Neurogenesis in the rat brain: bromodeoxyuridine (BrdU) incorporation into the nuclei of dividing cells and co-localized with the glial marker primary antiglial fibrillary acidic protein (GFAP) antibody to exclude the presence of glial BrdU labeling
| Hippocampus growth factors, such as IGF-1 and IGF-1R levels, and extracellular-signal-regulated-kinase (ERK) activation
Other outcomes reported
Results | RAWM performances:
| Repeated measures analysis across days revealed a significant day effect for latency (p<0.0001) suggesting that rats in both groups could successfully learn the task on days 1–3. The lack of interaction between groups (p<0.744) suggested that the rate of learning on days 1–3 did not differ across groups. On day 4, compared to animals fed the control diet, blueberry-fed rats had significantly fewer reference memory errors (p<0.05) and total memory errors (p<0.05), and also showed a trend towards fewer working memory errors (p<0.06). No significant difference in RAWM performances was seen between groups on day 5.
| Neurogenesis:
| Short-term blueberry supplementation significantly increased proliferation of precursor cells in the dentate gyrus of aged rats (p<0.05). Pearson's correlations revealed that, as the number of proliferating cells increased, the number of memory errors on Day 4 decreased (reference memory errors: r=-<0.684, p<0.05; working memory errors: r=-<0.646, p<0.05; total memory errors: r=-<0.677, p<0.05).
| IGF-1 and IGF-1R levels:
| A significant increase in the levels of IGF-1 protein by blueberry supplementation compared to the control rats (p<0.001). Increased IGF-1 levels were associated with significant decreases in memory errors (total memory errors: r=-0.626, p<0.05). and trends towards decreased reference memory errors (r=-0.539, p<0.09) and working memory errors (r=-0.581, p<0.07).
| There was a statistically significant positive correlation between ERK activation and IGF-1 levels (r=0.748, p<0.05).
| There were no significant correlations between levels of IGF-1 and proliferation.
| Levels of IGF-1R in blueberry-supplemented rats were significantly increased compared to the control rats (p<0.05), and correlated with levels of IGF-1 (r=0.788, p<0.01). The increase in IGF-1R were associated with decreases in total memory errors (r=-0.375, p<0.05) and reference memory errors (r=0.738, p<0.01) but not working memory errors (r=-0.545, p<0.104) on day 4.
| There was a statistically significant positive correlation between ERK activation and IGF-1R levels (r=0.722, p<0.05) but not proliferation.
| ERK activation:
| There was a significant increase of ERK activation by blueberry supplementation (p<0.01). The increase in ERK activation were related to decreases in total memory errors (r=-0.629, p<0.05) and reference memory errors (r=-0.636, p<0.05) but not working memory errors (r=-0.537, p<0.109) on day 3. Proliferation was not significantly correlated with ERK activation.
Authors' Conclusions | Blueberry supplementation → increase IGF-1, IGF-1R, and ERK activation → decreases in total memory errors and reference memory errors but NOT working memory errors on day 4
| Increase IGF-1, IGF-1R, and ERK activation are NOT associated with neurogenesis
| Blueberry supplementation → increased proliferation of precursor cells in the dentate gyrus of aged rats → decreases in total memory errors, reference memory errors, and working memory errors
Quality | A
Limitations / Comments | Correlate the “intermediate markers” to the neurocognitive measures!

Author, Year | Goyarzu, 2004
Central hypothesis/Stated Purposes of Study | (1) Aged rats on control diet will be impaired in object recognition memory, (2) The age-related impairment will be more severe with a longer delay between object presentation and preference testing (maximizing memory demand), (3) Aged rats on control diet will have elevated cytosolic NF-κB levels in several brain regions, (4) For months of diet supplementation with antioxidant-rich blueberry extract will significantly reduce both the age-related memory impairment and the elevation of NF-κB
Hypothesis diagram | Supplementation of blueberry extract → reduced the elevation of NF-κB (a indicator of oxidative stress) → reduced age-related memory impairment
Experimental diets or reagents | 2% blueberry supplemented to NIH-31 rodent chow. 200 g/week.
Control diets or reagents | 2% dried corn supplemented to NIH-31 rodent chow. 200 g/week.
Study characteristics | Country: US
| Funding source: University funded
Gap in Knowledge | Known: The protein transcription factor, nuclear factor-kappa B (NF-κB) is a highly responsive indicator of oxidative stress (OS). Increased NF-κB activity may constitute a protective response, buffering the effects of OS as induction of apoptosis and mitochondrial dysfunction.
| Unknown:
Experimental model | Aged subjects: 15-month-old male virgin Fischer-344 rats (19-months old at time of testing)
| Young subjects: 4-month-old male virgin Fischer-344 rats (8-months old at time of testing)
Study design | For 4 months prior to testing, 12 young rats were maintained on the control diet. 12 aged rats were maintained on the control diet, while 12 aged rats were fed the BB-supplemented diet.
Final sample size | Young Ctrl: 12 | Aged Ctrl: 12 | Aged BB: 12
Duration | 4 months
Measurements / Endpoints / Outcomes of interest | Object recognition memory: Ennaceur and Delacour (1988) introduced a non-spatial object recognition memory task that test a rat's recognition memory for having previously encountered and explored an object. The procedure exploits the innate tendency of rats to preferentially explore novel vs. familiar objects. Young rats spend much more time closely exploring the novel object than the familiar object.
| NF-κB levels in the brain: 4 days after the conclusion of behavioral testing, subjects were perfused with saline, Brains were removed and dissected into 3 different regions, including the frontal cortex, hippocampus, basal forebrain, striatum and cerebellum.
Other outcomes reported | Weight gain
Results | Object recognition memory:
| All 3 groups showed significantly greater than chance preference for the novel object with a 30-s training-test delay, but only in the young rats and the BB diet aged rats with a 1-h delay.
| Pair-wise post-hoc comparisons (Fisher's LSD test) of object recognition scores after the 30-s delay revealed no significant differences among the 3 groups.
| Pair-wise post-hoc comparisons of object recognition scores after the 1-h delay revealed that young rats had significantly higher object recognition memory scores than aged rats on the control diet (p<0.01). The blueberry-supplemented aged rats also had significantly higher object recognition memory scores than aged rats on the control diet (p<0.01). There is no significant difference between the young rats and the blueberry-supplemented aged rats.
| NF-κB levels in the brain:
| In every region, aged rats maintained on the control diet had higher NF-κB levels than young rats maintained on the control diet.
| In every region, aged rats maintained on the BB-enriched diet had lower NF-κB levels than aged rats maintained on the control diet. In all regions except the basal forebrain, this difference was significant.
| In the cerebellum, the aged rats maintained on the BB-enriched diet had significantly higher NF-κB levels than the young rats. However, in the other 4 regions, there was no significant difference between those 2 groups.
Authors' Conclusions | Blueberry supplementation eliminated the deficit in 19-month old rats, in that the aged the aged blueberry-supplemented rats, not only performed significantly above chance, but also performed as well as young rats.
| Blueberry supplementation attenuates the elevation of NF-κB levels in the aging rat brain.
Quality | A
Limitations / Comments

Author, Year | Joseph, 2004
Central hypothesis/Stated Purposes of Study | Blueberry and other fruit extracts may provide protection against Aβ 25–35 or dopamine (DA) in the COS-7 cell model.
Hypothesis diagram | Fruit extracts → reduce Aβ (25–35)- or DA- induced oxidative stress (OS ) through MAChRs
Experimental diets or reagents | 2 mg/ml blueberry (BB), 2 mg/ml black currant (BC), 2 mg/ml boysenberry (BY), or 0.5 mg/ml strawberry (SB), 1 mg/ml cranberry (CB) pre-treatments
Control diets or reagents | No pre-treatments
Study characteristics | Country: US
| Funding source: No data
Gap in Knowledge | Known: The effects of OS may occur at the receptor level. In this respect, experiments have shown that there is a loss of sensitivity in MAChRs as a function of age and AD, as well as aging. Recent findings have shown that COS-7 celss transfected with one of the 5 MAChRs and exposed to DA showed differences in OS sensitivity in calcium buffering. In 2 previous experiments, it was shown that antioxidants can prevent the loss of viability in COS-7 cells transfected with sensitive (M1AchR) muscarinic receptors and exposed to DA, and prevent the decrease in Recovery in M1AchR-transfected COS-7 cells exposed to Aβ (25–35, 100 μM).
| Unknown: if similar protection (described above) could be achieved against Aβ (25–35, 100 μM) or DA exposure in M1AchRtransfected COS-7 cells following pre-treatment with various fruit extracts that have high antioxidant activity.
Experimental model | COS-7 cells (ATCC) transfected with rat muscarinic receptor subtype 1 or 3 DNA by the DEAE-dextran method
Study design | In vitro: Each fruit extract was dissolved in growth media and M1AchR-transfected COS-7 cells were subsequently incubated for 45 min at 37 °C with the treated growth medium. Following these incubations the cells were washed 3 times with extract-free growth medium prior to testing. Note that no repeated measures were utilized in these studies.
Final sample size | N/A
Duration | N/A
Measurements / Endpoints / Outcomes of interest | Ca^2+^ Recovery following 0 or 1 mM DA treatment: Recovery was determined by assessing the time (within 300 sec) for the Ca^2+^ level to return to 20% of the increase following depolarization in the cells that responded.
| Ca^2+^Recovery following 0 or 100 μM Aβ (25–35) treatment
| % Viability following 0 or 1 mM DA treatment: Viability of the cell at 24 hrs following a 4 hr exposure to 1 mM DA was determined using the Live/Dead Eukolight Viability/Cytotoxicity Kit (Molecular Probes, Eugene, OR) without detaching the cells from the 35 mm plates.
Other outcomes reported
Results | In the absence of pre-treatment (control condition) there were significant effects of both DA and Aβ on Recovery of the M1- transfected cells (e.g., control vs. DA- or Aβ-treated cells with no extract pre-treatment, p<0.001).
| In comparisons with the non-preteated DA-exposed cells, all of the fruit extract pre-treatments were effective in offering some protection. However, compared to their own respective controls (not exposed to DA) only BB, and BY were totally protective against the DA.
| The BB-pre-treatment was the most effective in protecting against the effects of Aβ on Recovery (e.g., BB+Aβ vs. BB control,p>0.05; BB+Aβ vs. control, p>0.05; BB+Aβ vs. Aβ, p<0.05).
| The Recovery in the BC+Aβ cells did not differ from their respective controls (p>0.05), while the cells pre-treated with BY and exposed to Aβ showed lower Recovery than their respective controls (p<0.05)
| SB did not offer protection against Aβ and the cell exposed to Aβ and pre-treated with SB showed lower Recovery than theirrespective controls (p<0.05).
| BB and BY showed the strongest effects in protecting the DA-treated cells against loss of viability (e.g., BB+Aβ treated vs. non-DA, non-BB-treated, p>0.05). The effects of the other extracts (i.e., CB, BC, and SB) were similar except that the DA-exposed cellspre-treated with these extracts showed lower viability than that seen in their respective non-DA treated controls.
Authors' Conclusions | The results from the present study indicate that it may be possible to reduce both the deleterious effects of DA and the putative toxic effects of Aβ via fruits high in antioxidant activity. Each of these fruit extracts showed some degree of protection against the deleterious effects of DA on Recovery, with SB showing the weakest effects. The most efficacious extracts were BB and BY which were totally protective against the effects of DA, as compared to their own respective controls.
| BB pre-treatment was also the most beneficial in protecting against the effects of Aβ on Recovery, while, unlike the effects seen with DA, BC exceeded those of BY and GR effects were negative. As with DA exposure, SB showed very little protective effect against Aβ on Recovery.
| In the case of Viability, the M1-transfected COS-7 cells showed similar effects to that seen with respect to Recovery, with BB and BY showing the strongest effects.
Quality | B
Limitations / Comments | The study also had 0.5 mg/ml dried plum and 0.05 mg/ml grape (GR) pre-treatments but they are not of interest to this report. Note that no repeated measures were utilized in these studies.

Author, Year | Rabin, 2005A
Central hypothesis/Stated Purposes of Study | To evaluate the effects of strawberry and blueberry supplementation on operant performance in rats exposed to 1.5 Gy of ^56^Fe particles. Specifically, (1) would antioxidant diets be equally effective following exposure to a higher dose of heavy particles, which presumably produce a greater level of oxidative stress? (2) What would be the nature of the interaction with the age of the animal at the time of testing?
Hypothesis diagram | Heavy particle irradiation → neurobehavioral deficits due to accelerated oxidative stress. Berry antioxidants may be protective.
Experimental diets or reagents | Blueberry (BB) diet: 2% of the control diet was supplemented with blueberry extract. Overall this was equivalent to the consumption of 4 g of BB (1 kg of whole BB yielded 110 g of BB extract, assuming that rats consumed approximately 20 g diet/day). Berry homogenate replaced corn in NIH-31 diet.
| Strawberry (SB) diet: 2% of the control diet was supplemented with strawberry extract.
Control diets or reagents | NIH-31
Study characteristics | Country: US
| Funding source: National Aeronautics and Space Administration (NASA)
Gap in Knowledge | Known: Exposure to heavy particles such as ^56^Fe produces deficits in neurobehavioral function which are characteristic of the aged organism.
| Unknown: Whether high anti-oxidant diet, in the form of blueberries or strawberries, can mitigate effect of radiation
Experimental model | Male Sprague-Dawley rats weighing 175–200 g
Study design | Rats were placed on a diet containing blueberry extract, or strawberry extract, or on a control diet for 2 months prior to irradiation.
| The rats were irradiated with 1.5 Gy of ^56^Fe. After exposure the rats were trained and tested on the operant task.
| After exposure, all rats were placed on non-berry supplement diets.
Final sample size | BB+^56^Fe: 10 | SB+^56^Fe: 10 | Ctrl+^56^Fe: 10
| BB: 10 | SB: 10 | Ctrl: 10
| Several rats, particularly among those irradiated & on control diet, were euthanized before completion due to tumor development
Duration | 12 months after irradiation
Measurements / Endpoints / Outcomes of interest | Operant task: The rats were food deprived to 85%–90% of their base weight and trained to lever press for a 45-mg food pellet using an autoshaping procedure, which was followed by training to respond on an Fixed-Ratio (FR) reinforcement schedule. Once this response had been acquired, the rats were immediately tested on an ascending FR schedule for FR-1 to FR-35. 2 replications were carried out at 6 and 12 months postirradiation.
Other outcomes reported
Results | When tested 6 months after irradiation, all groups, irrespective of diet or irradiation status performed equally.
| At 12 months after irradiation, irradiated rats fed strawberries performed equally well as non-irradiated rats. Irradiated rats fed blueberries or control diet performed equally poorly compared to the other groups.
Authors' Conclusions | Disruption of operant performance (specifically response to an ascending fixed ratio schedule) by heavy particle irradiation in older rats can be prevented by maintaining rats on a diet containing 2% strawberry extract, but not blueberry extract.
| Lack of difference among diets and radiation status at 6 months was expected from previous research indicating that the deleterious effects of exposure to 1.5 Gy of ^56^Fe particles occurs among older rats.
Quality | A
Limitations / Comments | Unclear whether exposure to heavy particles is an appropriate model for human neurocognitive disease while on Earth.

Medline UI 15725409

Author, Year | Rabin, 2005B
Central hypothesis/Stated Purposes of Study | To evaluate the effects of strawberry and blueberry supplementation on operant performance in rats exposed to 2.0 Gy of ^56^Fe particles. Specifically, (1) would antioxidant diets be equally effective following exposure to a higher dose of heavy particles, which presumably produce a greater level of oxidative stress? (2) Would the previously obtained difference in the effectiveness of the strawberry diet compared to the blueberry diet be observed in an independent experiment using a higher dose of radiation? (3) What would be the nature of the interaction with the age of the animal at the time of testing?
Hypothesis diagram | Heavy particle irradiation → neurobehavioral deficits due to accelerated oxidative stress. Berry antioxidants may be protective.
Experimental diets or reagents | Blueberry (BB) diet: 2% of the control diet was supplemented with blueberry extract. Overall this was equivalent to the consumption of 4 g of BB (1 kg of whole BB yielded 110 g of BB extract, assuming that rats consumed approximately 20 g diet/day).
| Strawberry (SB) diet: 2% of the control diet was supplemented with strawberry extract.
Control diets or reagents | NIH-31
Study characteristics | Country: US
| Funding source: National Aeronautics and Space Administration (NASA)
Gap in Knowledge | Known: Exposure to heavy particles such as ^56^Fe produces deficits in neurobehavioral function which are characteristic of the aged organism. Deleterious effects mitigated by X diet after 1.5 Gy irradiation
| Unknown: Effect of berry diets after higher dose irradiation.
Experimental model | Male Sprague-Dawley rats weighing 175–200 g
Study design | Rats were placed on a diet containing blueberry extract, or strawberry extract, or on a control diet for 2 months prior to irradiation. The rats were irradiated when they were about 3.5 to 4.0 months of age with 2.0 Gy of ^56^Fe. Following exposure the rats were trained and tested on the operant task.
| After exposure, the rats were fed a diet of standard lab chow (Purina 5100).
Final sample size | BB+^56^Fe: 8 | SB+^56^Fe: 8 | Ctrl+^56^Fe: 8
| BB: 4 | SB: 4 | Ctrl: 8
| Several rats, particularly among those irradiated & on control diet, were euthanized before completion due to tumor development
Duration | 18 months after irradiation
Measurements / Endpoints / Outcomes of interest | Operant task: The rats were food deprived to 85%–90% of their base weight and trained to lever press for a 45-mg food pellet using an autoshaping procedure, which was followed by training to respond on an Fixed-Ratio (FR) reinforcement schedule. Once this response had been acquired, the rats were immediately tested on an ascending FR schedule for FR-1 to FR-35. 4 replications were carried out: 5, 8, 13 and 18 months postirradiation.
Other outcomes reported
Results | Significant interactions were found between diet (combined berry vs control), irradiation (vs non-irradiation), and testing replication time (5, 8, 13, and 18 months after irradiation and initial training, i.e., age).
| When tested 5 and 8 months after irradiation (9 and 12 months of age), irradiated rats fed strawberries performed equally well as non-irradiated rats. Irradiated rats fed blueberries or control diet performed equally poorly compared to the other groups.
| At 13 and 18 months after irradiation, there was a decrement in the performance of the irradiated rats consuming strawberries compared to those on the blueberry diet; although their performance remained somewhat better. Comparison with irradiated rats on control diet could not be made because all but 2 of these animals died.
Authors' Conclusions | Disruption of operant performance (specifically response to an ascending fixed ratio schedule) by heavy particle irradiation can be prevented by maintaining rats on a diet containing 2% strawberry extract, but not blueberry extract.
| Similar to previous results found with exposure to 1.5 Gy of ^56^Fe, except that difference between diets is found at an earlier age.
Quality | A
Limitations / Comments | Unclear whether exposure to heavy particles is an appropriate model for human neurocognitive disease while on Earth.

Not in Medline or CAB abstracts

Author, Year | Shukitt-Hale, 2005
Central hypothesis/Stated Purposes of Study | To determine whether the beneficial effects of blueberries would also be seen with other berry fruits as compared with a control diet.
Hypothesis diagram
Experimental diets or reagents | 2% of the control diet was supplemented with blueberry (BB), blackcurrant (BC), boysenberry (BS) or cranberry (CB) extracts. The anthocyanin and total phenolic concentration present in the extracts are as blow:
| Berryfruit type | Total anthocyanin concentration (mg/g) | Total phenolic (325 nm) concentration (mg/g)
| Blueberry | 1.3 | 1.2
| Blackcurrant | 8.7 | 2.9
| Boysenberry | 9.2 | 2.0
| Cranberry | 3.3 | 3.6
Control diets or reagents | NIH-31 (20 g/kg)
Study characteristics | Country: US
| Funding source: USDA, Cranberry Institute; The Horticulture and Food Research Institute of New Zealand
Gap in Knowledge | Known: Previous studies have shown that increasing the levels of inducible hippocampal heat shock protein 70 (HSP70) can protect cells from numerous insults ranging from ischemia, inflammatory agents and reactive oxygen species.
| Unknown: The loss of the ability of cells to respond to these insults by increasing HSP70 may contribute to the age-related declines in both neuronal and behavioral functioning.
Experimental model | 19-month-old Male Fischer 344 rats
Study design | Weight-matched rats were placed on 3 separate diets (BB, BC, BS, CB or control diets) for 13–16 weeks total
Final sample size | No data
Duration | 13–16 weeks
Measurements / Endpoints / Outcomes of interest | Psychomotor testing, including (1) Rod Walk, (2) Wire Suspension, (3) Plank Walk, (4) Inclined Screen; (5) Accelerating Rotarod.
| Morris Water Maze (MWM), an accepted method of testing spatial learning and memory, is an age- and diet-sensitive learning paradigm that requires rats to find the location of a hidden platform just below the surface of a circular pool of water based on distal cues in previous learning trials.
| Hippocampal heat shock protein 70 (HSP70): in vitro LPS (Lipopolysaccharide) treatment (a stressor)
| Dopamine release
Other outcomes reported
Results | Of the psychomotor testing, only the inclined screen yielded significant results between diet groups. BB (p=0.038) and CB (p=0.001) groups performed significantly better than the control group.
| Morris Water Maze performance showed no differences among the diet groups.
| Dopamine release was different among the groups. Post-hot testing found that the BC (p=0.004) and CB (p=0.007) groups were significantly better than the control and BS groups. The effects of BB supplementation on striatal dopamine were not examined in this study, since it had been replicated in previous studies.
| Percent change in HSP70 also showed differences among the groups. Post-hot analyses showed that HSP70 responsiveness in the BB group was significantly higher than the control group (p=0.001), which the CB group showed a trend toward being higher than the control group (p=0.06). Furthermore, HSP70 levels positively correlated with inclined screen performance; i.e. latency to fall from the inclined screen increased as the percent change in HSP70 increased (r=0.39, p=0.048)
Authors' Conclusions | There were significant effects of the diets found on several of the measures in this study. The inclined screen, dopamine release and HSP70 results all suggest that there is a range of effectiveness associated with the different berryfruit diets. However, it does not appear that the anthocyanin component is the one solely responsible for these improvements, as the blackcurrant and boysenberry fruits are higher in anthocyanin level, but not as effective in improving motor performance. Future studies should examine other components, such as the proanthocyanidins and flavans, in addition to the anthocyanins.
Quality | B
Limitations / Comments | Sample size was not reported.

## Berry Evidence Tables - Human Studies

Author, Year: Golbe, 1988 | Ref ID: 15294 | Berries /Constituents: Blueberries and strawberries
Objective:To examine the hypothesis that Parkinson's disease may be cased by an amino acid chemically related to L-β-methyl-amino-alanine present in 1 or more fruits and vegetables common in the Western diet.

Study characteristics | | Population | | Controls | Inclusion criteria | Exclusion criteria | Definitions
Studydesign | Case-control study | Age: | 62.3±9.2 | 62.0±9.8 | Cases: | Cases-control pairs: | AD:
| Comparative | %Male: | 59.3 | 59.3 | PD patients | Either member was not married before age 40 years or was demented.
| Retrospective | Race: | ND | ND | | | PD: A diagnosis of idiopathic PD was confirmed by a neurologist specializing in movement disorders
Country: | US | Other: | | | Controls: Same-sex siblings of the cases who were nearest in age and willing and able to cooperate | | VascDz:
Setting: | Outpatients | | | | | | Other:
Funding: ND
Comments:

Predictor(s): | | Outcome(s): | | | Total | Population of interest | Control
| | | | N enrolled: | 162 | 81 | 81
More or less likely to consume a food (a list of fruits & vegetables) | P>Sib if P>Sp and Sib<SibSp; P>Sp and SibN; P=Sp and Sib<SibSp; or p=Sp and SibN. P<Sib if P<Sp and Sib>SibSp; PN and Sib>SibSp; P<Sp and Sib=SibSp, or PN and Sib=SibSp. | OR of PD in those more likely to eat the food to those less likely to eat the food | Mantel-Haenszel method | N analyzed: | 162 | 81 | 81
| | | | Drop-outs (%): | N/A
Comments: | Patients and same-sex siblings, in separate interviews, were each asked whether they or their spouse was more likely to eat each item between the time of marriage and age 40 ages. The spouses of patients and same-sex siblings were also interviewed for their dietary habit as internal standard.
| A reliability research of the method was conducted before the study in 15 patients with PD and their spouses. An item was discarded when less than 70% the pairs agreed on which member was more likely to eat that food item.

Other predictors/outcomes reported (if applicable):
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:. | Unusual definition of the consumption levels. Too many potential measurement errors due to the study and survey-method designs. The observations should be due to random errors
Quality (A/B/C): C | Applicability (1/2/3): 2

Outcome(s): | Results (Text)
OR of PD | There was no significant association between preference for consuming blueberries or strawberries and the risk of Parkinson's disease.

Case-Control Pairs Discordant for Preference (Relative to Spouse) for Various Fruits and Vegetables

| Pt>Sib | Pt<Sib | Odds Ratio | P
Blueberries | 13 | 21 | 0.62 | NS
Strawberries | 5 | 12 | 0.42 | NS

* see “Predictors” for the definitions for Pt>Sib and Pt<Sib

Keys: P>Sp, patient more likely than spouse to eat item; P=Sp, patient as likely as spouse to eat item and both did eat item; P<Sp, patient less likely than spouse to eat item; PN, neither the patient nor spouse ate item. Sib>SibSp, sibling more likely than his or her own spouse to eat item; Sib=SibSp, sibling as likely as spouse to eat item and both did eat item; Sib<SibSp, sibling less likely than spouse to eat item; SibN, neither the sibling nor his or her spouse ate item.