# Appendix B. Sample Data Extraction Forms

[underlined: Human Intervention Studies]

Author, Year: | Ref ID: | Vitamins:
Objective:

Study characteristics | Population | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | Age: | | | | AD:
Country: | %Male: | | | | PD:
Setting: | Race: | | | | VascDz:
Funding: | Other: | | | | Other:
Comments:

Intervention(s): | Control: | | Total | Intervention 1 | Intervention 2 | Control
| | N enrolled:
| | N analyzed:
| | Drop-outs (%):
Follow-up duration: | | Reasons for drop out:
Comments:

Primary outcome(s):
Secondary outcome(s):
Adverse events:
Limitations:
Quality (A/B/C): | Applicability (1/2/3):

Outcome(s): | Results (Text) (or Definition)

Outcome | | (units)
| | N | (Intervention) | (Dose) | N | (Intervention) | (Dose) | N | (Intervention) | (Dose) | N | Control
Baseline value | (SE/SD)
Final value | (SE/SD)
Difference | (SE/SD/95% CI)
P Difference
Net Difference | (SE/SD/95% CI)
P Net difference
(RR/OR/HR) | 95% CI
P (RR/OR/HR)

IN THIS TABLE, REPLACE ITEMS IN PARENTHESES WITH ACTUAL ITEMS (EG, Vitamin B6, SE, RR)

REMOVE PARENTHESES!! DOSE GOES IN TOP LINE. 2nd CELL IS FOR SE or SD

[underlined: Human - Correlation Studies]

Author, Year: | Ref ID: | Vitamins:
Objective:

Study characteristics | | Population | Controls | Inclusion criteria | Exclusion criteria | Definitions
Study design | XS/Longitudinal | Age: | | Cases: | Cases: | AD:
| Non-c/Comparative | %Male:
| Pro/Retrospective | Race: | | | | PD:
Country: | | Other: | | Controls: | Controls: | VascDz:
Setting: | | | | | | Other:
Funding:
Comments:

Predictor(s): (eg, B vit level) | Outcome(s): | Definition: | | Total | Population of interest | Control
| | | N enrolled:
| | | N analyzed:
| | | Drop-outs (%):
Comments:

Other predictors/outcomes reported:
Follow-up duration (if applicable):
Reasons for drop out (if applicable):
Limitations:
Quality (A/B/C): | Applicability (1/2/3):

Outcome(s): | Results (Text)

Correlation of Predictors with Outcomes (cross-sectional studies)

Description of (Sub-) Groups | N | (Sr/CSF) | (B vit) | (unit) | p | (Sr/CSF) | (B vit) | (unit) | p | (Sr/CSF) | (B vit) | (unit) | (Sr/CSF) | (B vit) | (unit) | p
| | Mean | SE/SD | r= | | Mean | SE/SD | r= | | Mean | SE/SD | r= | Mean | SE/SD | r=

IN THIS TABLE, REPLACE ITEMS IN PARENTHESES WITH ACTUAL ITEMS (EG, Vitamin B6, SE, RR)

REMOVE PARENTHESES!!

Description of (Sub-) Groups | N | (Outcome) | | N | (Outcome)
| | OR (Adj 1*) | OR (Adj 2*) | | OR (Adj 1*) | OR (Adj 2*)
(Reference gp) | | 1 | 1 | | 1 | 1
(Reference gp) | | 1 | 1 | | 1 | 1

* Adj 1, adjusted for ...

[underlined: Animal and In Vitro Studies]

Author, Year
Central hypothesis/Stated Purposes of Study
Hypothesis diagram
Experimental diets or reagents
Control diets or reagents
Study characteristics | Country:
| Funding source:
Gap in Knowledge | Known:
| Unknown:
Experimental model
Study design
Final sample size
Duration
Measurements / Endpoints / Outcomes of interest
Other outcomes reported
Results
Authors' Conclusions
Quality
Limitations / Comments