# Appendix A. Literature Search Strings

## B Vitamins (Feb 2, 2005)

Ovid MEDLINE® <1966 to Jan Week 3 2005>

Ovid MEDLINE® Daily Update <Jan 31, 2005>

Ovid MEDLINE® In-Process & Other Non-Indexed Citations <Jan 31, 2005>

CAB Abstracts <1973 to Dec 2004>

# | Search History | Results
1 | exp nervous system diseases/ | 1259232
2 | exp Delirium, Dementia, Amnestic, Cognitive Disorders/ | 93503
3 | neuron$.mp. | 329067
4 | nerve cell$.mp. | 7813
5 | alzheimer$.mp. | 46029
6 | lewy bod$.mp. | 2629
7 | brain.mp. | 639058
8 | dementia.mp. | 48550
9 | neurodegen$.mp. | 17734
10 | or/1–9 | 1822067
11 | exp folic acid/ | 21806
12 | (folate or folic acid or pteroylglutamic or folacin).mp. | 28501
13 | exp Riboflavin/ | 9878
14 | (Riboflavin or lactoflavin).mp. | 11051
15 | exp Thiamine/ | 9522
16 | Thiamine.mp. | 11080
17 | exp Vitamin B 12/ | 11454
18 | cobalamin$.mp. | 2944
19 | cyanocobalamin$.mp. | 1297
20 | exp Vitamin B 6/ | 10645
21 | exp PYRIDOXINE/ | 8461
22 | (pyridoxal or pyridoxamine or pyridoxine).mp. | 17309
23 | (vitamin adj1 (“B1” or “B 1” or “B2” or “B 2” or “B6” or “B 6” or “B12” or “B 12”)).mp. | 26741
24 | or/11–23 | 84479
25 | 10 and 24 | 11080
26 | limit 25 to English language | 8984
27 | limit 26 to (addresses or bibliography or biography or case reports or clinical conference or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index or “review of reported cases”) [Limit not valid in: CAB Abs; records were retained] | 1762
28 | 26 not 27 | 7222
29 | remove duplicates from 28 | 6640

## Berries (Mar 3, 2005)

Ovid MEDLINE® <1966 to Feb Week 4 2005>

Ovid MEDLINE® Daily Update <Mar 02, 2005>

Ovid MEDLINE® In-Process & Other Non-Indexed Citations <Mar 02, 2005>

CAB Abstracts <1973 to Jan 2005>

# | Search History | Results
1 | exp nervous system diseases/ | 1265160
2 | exp Delirium, Dementia, Amnestic, Cognitive Disorders/ | 94198
3 | neuron$.mp. | 331088
4 | nerve cell$.mp. | 7842
5 | alzheimer$.mp. | 46489
6 | parkinson$.mp. | 42926
7 | lewy bod$.mp. | 2651
8 | brain.mp. | 642015
9 | dementia.mp. | 48839
10 | neurodegen$.mp. | 18012
11 | or/1–10 | 1837302
12 | limit 11 to English language | 1483695
13 | exp blueberry plant/ | 33
14 | blueberr$.mp. | 3182
15 | cranberr$.mp. | 1275
16 | lingonberr$.mp. | 176
17 | bilberr$.mp. | 554
18 | marionberr$.mp. | 11
19 | exp vaccinium/ | 5126
20 | vaccinium.mp. | 5781
21 | strawberr$.mp. | 15298
22 | exp fragaria/ | 12515
23 | fragaria.mp. | 12692
24 | raspberr$.mp. | 5253
25 | blackberry.mp. | 1209
26 | ribes.mp. | 4419
27 | currant$.mp. | 3972
28 | boysenberr$.mp. | 116
29 | or/13–28 | 30056
30 | exp Flavonols/ | 6888
31 | flavonol$.mp. | 3880
32 | exp flavonoids/ | 48492
33 | flavonoid$.mp. | 27766
34 | proanthocyan$.mp. | 1545
35 | anthocyan$.mp. | 8069
36 | leucoanthocyan$.mp. | 294
37 | catechin$.mp. | 5272
38 | epicatechin$.mp. | 1849
39 | quercetin$.mp. | 7303
40 | myricetin$.mp. | 765
41 | procyan$.mp. | 1024
42 | flavonol$.mp. | 3880
43 | biflavonoid$.mp. | 635
44 | flavanone$.mp. | 2305
45 | flavonolignan$.mp. | 101
46 | flavan-3-ol$.mp. | 406
47 | phytochemical$.mp. | 5036
48 | exp cinnamates/ | 10537
49 | cinnamate$.mp. | 2988
50 | hydroxycinnamate$.mp. | 507
51 | chlorogenic$.mp. | 2546
52 | Kaempferol$.mp. | 2550
53 | Rutin$.mp. | 3963
54 | Hydroxyethylrutoside$.mp. | 329
55 | cyanidin$.mp. | 1253
56 | malvidin$.mp. | 419
57 | petunidin$.mp. | 221
58 | phloridzin$.mp. | 611
59 | delphinidin$.mp. | 588
60 | ferulic$.mp. | 3010
61 | peonidin$.mp. | 342
62 | resveratro$.mp. | 1819
63 | Pulchellidin$.mp. | 3
64 | or/30–63 | 76600
65 | 12 and (29 or 64) | 2627
66 | exp nervous system/ | 1082233
67 | limit 66 to English language | 928559
68 | (12 or 67) and (29 or 64) | 3496
69 | 70 not 66 | 875
70 | pterostilbene$.mp. | 44
71 | (flavan$ or tannin$ or phytonutri$).mp. | 17564
72 | (70 or 71) and (12 or 67) | 361
73 | 76 not (66 or 69) | 221
74 | exp gooseberry/ | 24
75 | gooseberr$.mp. | 1431
76 | (74 or 75) and (12 or 67) | 19
77 | 81 not (66 or 69 or 73) | 18
78 | exp fruit/ | 44312
79 | fruit$1.mp. | 290648
80 | “fruit fly”.mp. | 4006
81 | (78 or 79) not 80 | 299608
82 | 87 and 12 | 1016
83 | 89 not (65 or 68 or 72 or 76) | 922
84 | or/65,69,73,77, 83 | 4633