# Appendixes

Appendix A. Literature Search Strings

Appendix B. Sample Data Extraction Forms

Appendix C. Evidence Tables

Appendix D. List of Excluded Studies

Appendix E. Peer Reviewers