# References for Evidence Tables

Allen VM, O'Connell CM, Liston RM, Baskett TF. Maternal morbidity associated with cesarean delivery without labor compared with spontaneous onset of labor at term. Obstet Gynecol. 2003;102(3):477-82. [pmid: 12962927].
Badawi N, Kurinczuk JJ, Keogh JM, et al. Intrapartum risk factors for newborn encephalopathy: the Western Australian case-control study. Br Med J. 1998;317(7172):1554-8. [pmid: 9836653]. [pmcid: 28733].
Bergholt T, Stenderup JK, Vedsted-Jakobsen A, Helm P, Lenstrup C. Intraoperative surgical complication during cesarean delivery: an observational study of the incidence and risk factors. Acta Obstet Gynecol Scand. 2003;82(3):251-6. [pmid: 12694122].
Burrows LJ, Meyn LA, Weber AM. Maternal morbidity associated with vaginal versus cesarean delivery. Obstet Gynecol. 2004;103(5 Pt 1):907-12. Rec #: 9598. [pmid: 15121564].
Dani C, Reali MF, Bertini G, et al. Risk factors for the development of respiratory distress syndrome and transient tachypnoea in newborn infants. Italian Group of Neonatal Pneumology. Eur Respir J. 1999;14(1):155-9. [pmid: 10489844].
Dessole S, Cosmi E, Balata A, et al. Accidental fetal lacerations during cesarean delivery: experience in an Italian level III university hospital. Am J Obstet Gynecol. 2004;191(5):1673-7. [pmid: 15547541].
Durik AM, Hyde JS, Clark R. Sequelae of cesarean and vaginal deliveries: psychosocial outcomes for mothers and infants. Dev Psychol. 2000;36(2):251-60. [pmid: 10749082].
Farrell SA, Allen VM, Baskett TF. Anal incontinence in primiparas. J Soc Obstet Gynaecol Can. 2001;23(4):321-6.
Farrell SA, Allen VM, Baskett TF. Parturition and urinary incontinence in primiparas. Obstet Gynecol. 2001;97(3):350-6. [pmid: 11239635].
Fawcett J, Pollio N, Tully A. Women's perceptions of cesarean and vaginal delivery: another look. Res Nurs Health. 1992;15(6):439-46. [pmid: 1448575].
Golfier F, Vaudoyer F, Ecochard R, Champion F, Audra P, Raudrant D. Planned vaginal delivery versus elective caesarean delivery in singleton term breech presentation: a study of 1116 cases. Eur J Obstet Gynecol Reprod Biol. 2001;98(2):186-92. [pmid: 11574129].
Groutz A, Rimon E, Peled S, et al. Cesarean delivery: does it really prevent the development of postpartum stress urinary incontinence? A prospective study of 363 women one year after their first delivery. Neurourol Urodyn. 2004;23(1):2-6. [pmid: 14694448].
Hannah ME, Hannah WJ, Hewson SA, et al. Planned caesarean delivery versus planned vaginal birth for breech presentation at term: a randomised multicentre trial. Term Breech Trial Collaborative Group. Lancet. 2000;356(9239):1375-83. [pmid: 11052579].
Hannah ME, Hannah WJ, Hodnett ED, et al. Outcomes at 3 months after planned cesarean vs planned vaginal delivery for breech presentation at term: the international randomized Term Breech Trial. JAMA. 2002;287(14):1822-31. [pmid: 11939868].
Hannah ME, Whyte H, Hannah WJ, et al. Maternal outcomes at 2 years after planned cesarean delivery versus planned vaginal birth for breech presentation at term: the international randomized Term Breech Trial. Am J Obstet Gynecol. 2004;191(3):917-27. [pmid: 15467565].
Hillan EM. Postoperative morbidity following Caesarean delivery. J Adv Nurs. 1995;22(6):1035-42. [pmid: 8675855].
Irion O, Hirsbrunner Almagbaly P, Morabia A. Planned vaginal delivery versus elective caesarean delivery: a study of 705 singleton term breech presentations. Br J Obstet Gynaecol. 1998;105(7):710-7. [pmid: 9692410].
Koroukian SM. Relative risk of postpartum complications in the Ohio Medicaid population: vaginal versus cesarean delivery. Med Care Res Rev. 2004;61(2):203-24. [pmid: 15155052].
Krebs L, Langhoff-Roos J. Elective cesarean delivery for term breech. Obstet Gynecol. 2003;101(4):690-6. [pmid: 12681872].
Lal M, Mann CH, Callender R, Radley S. Does cesarean delivery prevent anal incontinence?. Obstet Gynecol. 2003;101(2):305-12. [pmid: 12576254].
Leiberman JR, Fraser D, Mazor M, et al. Breech presentation and cesarean delivery in term nulliparous women. Eur J Obstet Gynecol Reprod Biol. 1995;61(2):111-5. [pmid: 7556830].
Levine EM, Ghai V, Barton JJ, et al. Mode of delivery and risk of respiratory diseases in newborns. Obstet Gynecol. 2001;97(3):439-42. [pmid: 11239653].
MacArthur C, Bick DE, Keighley MR. Faecal incontinence after childbirth. Br J Obstet Gynaecol. 1997;104(1):46-50. [pmid: 8988696].
MacArthur C, Glazener CM, Wilson PD, et al. Obstetric practice and faecal incontinence three months after delivery. BJOG. 2001;108(7):678-83. [pmid: 11467690].
Mason L, Glenn S, Walton I, Appleton C. The prevalence of stress incontinence during pregnancy and following delivery. Midwifery. 1999;15(2):120-8. [pmid: 10703415].
Morrison JJ, Rennie JM, Milton PJ. Neonatal respiratory morbidity and mode of delivery at term: influence of timing of elective caesarean delivery. Br J Obstet Gynaecol. 1995;102(2):101-6. [pmid: 7756199].
Nice C, Feeney A, Godwin P, et al. A prospective audit of wound infection rates after caesarean delivery in five West Yorkshire hospitals. J Hosp Infect. 1996;33(1):55-61. [pmid: 8738202].
Persson J, Wolner-Hanssen P, Rydhstroem H. Obstetric risk factors for stress urinary incontinence: a population-based study. Obstet Gynecol. 2000;96(3):440-5. [pmid: 10960639].
Phipps MG, Watabe B, Clemons JL, Weitzen S, Myers DL. Risk factors for bladder injury during cesarean delivery. Obstet Gynecol. 2005;105(1):156-60. [pmid: 15625157].
Reichert JA, Baron M, Fawcett J. Changes in attitudes toward cesarean birth. J Obstet Gynecol Neonatal Nurs. 1993;22(2):159-67.
Rubaltelli FF, Bonafe L, Tangucci M, et al. Epidemiology of neonatal acute respiratory disorders. A multicenter study on incidence and fatality rates of neonatal acute respiratory disorders according to gestational age, maternal age, pregnancy complications and type of delivery. Italian Group of Neonatal Pneumology. Biol Neonate. 1998;74(1):7-15. [pmid: 9657664].
Ryding EL, Wijma K, Wijma B. Psychological impact of emergency cesarean delivery in comparison with elective cesarean delivery, instrumental and normal vaginal delivery. J Psychosom Obstet Gynaecol. 1998;19(3):135-44. [pmid: 9844844].
Sanchez-Ramos L, Wells TL, Adair c/d, Arcelin G, Kaunitz AM, Wells DS. Route of breech delivery and maternal and neonatal outcomes. Int J Gynaecol Obstet. 2001;73(1):7-14. [pmid: 11336715].
Schindl M, Birner P, Reingrabner M, et al. Elective cesarean delivery vs. spontaneous delivery: a comparative study of birth experience. Acta Obstet Gynecol Scand. 2003;82(9):834-40. [pmid: 12911445].
Schytt E, Lindmark G, Waldenstrom U. Symptoms of stress incontinence 1 year after childbirth: prevalence and predictors in a national Swedish sample. Acta Obstet Gynecol Scand. 2004;83(10):928-36. [pmid: 15453888].
Sutton L, Sayer GP, Bajuk B, Richardson V, Berry G, Henderson-Smart DJ. Do very sick neonates born at term have antenatal risks? 2. Infants ventilated primarily for lung disease. Acta Obstet Gynecol Scand. 2001;80(10):917-25. [pmid: 11580736].
Towner D, Castro MA, Eby-Wilkens E, et al. Effect of mode of delivery in nulliparous women on neonatal intracranial injury. N Engl J Med. 1999;341(23):1709-14. [pmid: 10580069].
van Ham MA, van Dongen PW, Mulder J. Maternal consequences of caesarean delivery. A retrospective study of intra-operative and postoperative maternal complications of caesarean delivery during a 10-year period. Eur J Obstet Gynecol Reprod Biol. 1997;74(1):1-6. [pmid: 9243191].
Wilson PD, Herbison RM, Herbison GP. Obstetric practice and the prevalence of urinary incontinence three months after delivery. Br J Obstet Gynaecol. 1996;103(2):154-61. [pmid: 8616133].
Zanardo V, Simbi AK, Franzoi M, Solda G, Salvadori A, Trevisanuto D. Neonatal respiratory morbidity risk and mode of delivery at term: influence of timing of elective caesarean delivery. Acta Paediatr. 2004;93(5):643-7. [pmid: 15174788].
Zanardo V, Simbi KA, Vedovato S, Trevisanuto D. The influence of timing of elective cesarean delivery on neonatal resuscitation risk. Pediatr Crit Care Med. 2004;5(6):566-70. [pmid: 15530194].