# References and Included Studies

1 Hale RW, Harer WB Jr. Elective prophylactic cesarean delivery. ACOG Clin Rev 2005;10(2):1, 15, 16.
2 Martin JA, Hamilton BE, Menacker F, Sutton PD, Mathews TJ. Preliminary births for 2004: infant and maternal health. Hyattsville, MD: National Center for Health Statistics; 2005.
3 Meikle SF, Steiner CA, Zhang J, et al. A national estimate of the elective primary cesarean delivery rate. Obstet Gynecol. 2005;105(4):751-6. [pmid: 15802401].
4 Agency for Healthcare Research and Quality. AHRQ study finds quarter of cesarean sections may be performed too early in labor. Rockville, Md: Research Alert, March 31, 2000. Agency for Healthcare Research and Quality (AHRQ). http://www.ahrq.gov/news/press/pr2000/giffordpr.htm;2000.
5 Kalish RB, McCullough L, Gupta M, et al. Intrapartum elective cesarean delivery: a previously unrecognized clinical entity. Obstet Gynecol. 2004;103(6):1137-41. [pmid: 15172844].
6 FIGO Committee for the Ethical Aspects of Human Reproduction and Women's Health. Gynecol Obstet Invest 1999;48:73–7.
7 American College of Obstetricians and Gynecologists (ACOG). ACOG Committee Opinion. Surgery and patient choice: the ethics of decision making. Obstet Gynecol. 2003;102(5 Pt 1):1101-6. [pmid: 14672494].
8 Hoyert DL, Hsiang-Ching K, Smith BL. Deaths: preliminary data for 2003. Natl Vital Stat Rep. 2005;53(15):1-48.
9 Laughon K, Wolfe H, Visco AG. Why does a prior cesarean section increase the risk for placenta via a case-control study. Obstet Gynecol In press.
10 Zhang J, Savitz DA. Maternal age and placenta previa: a population-based, case-control study. Am J Obstet Gynecol. 1993;168(2):641-5. [pmid: 8438945].
11 Clark SL, Koonings PP, Phelan JP. Placenta previa/accreta and prior cesarean section. Obstet Gynecol. 1985;66(1):89-92. [pmid: 4011075].
12 Read JA, Cotton DB, Miller FC. Placenta accreta: changing clinical aspects and outcome. Obstet Gynecol. 1980;56(1):31-4. [pmid: 6966777].
13 Donnelly V, Fynes M, Campbell D, et al. Obstetric events leading to anal sphincter damage. Obstet Gynecol. 1998;92(6):955-61. [pmid: 9840557].
14 American College of Obstetricians and Gynecologists. ACOG unveils survey of women ob-gyns at media briefing. ACOG Today 2004;48(2):1, 6–7.
15 Sultan AH, Kamm MA, Bartram CI, et al. Anal sphincter trauma during instrumental delivery. Int J Gynaecol Obstet. 1993;43(3):263-70. [pmid: 7907036].
16 Sultan AH, Kamm MA, Hudson CN, et al. Anal-sphincter disruption during vaginal delivery. N Engl J Med. 1993;329(26):1905-11. [pmid: 8247054].
17 Dietz HP, Bennett MJ. The effect of childbirth on pelvic organ mobility. Obstet Gynecol. 2003;102(2):223-8. [pmid: 12907092].
18 Hannah ME, Hannah WJ, Hodnett ED, et al. Outcomes at 3 months after planned cesarean vs planned vaginal delivery for breech presentation at term: the international randomized Term Breech Trial. JAMA. 2002;287(14):1822-31. [pmid: 11939868].
19 Nielsen TF, Hokegard KH. Postoperative cesarean section morbidity: a prospective study. Am J Obstet Gynecol. 1983;146(8):911-5. [pmid: 6881224].
20 Hannah ME, Hannah WJ, Hewson SA, et al. Planned caesarean section versus planned vaginal birth for breech presentation at term: a randomised multicentre trial. Term Breech Trial Collaborative Group. Lancet. 2000;356(9239):1375-83. [pmid: 11052579].
21 Frigoletto FD Jr, Ryan KJ, Phillippe M. Maternal mortality rate associated with cesarean section: an appraisal. Am J Obstet Gynecol. 1980;136(7):969-70. [pmid: 7361846].
22 Sachs BP, Yeh J, Acker D, et al. Cesarean section-related maternal mortality in Massachusetts, 1954-1985. Obstet Gynecol. 1988;71(3 Pt 1):385-8. [pmid: 3347424].
23 Lilford RJ, van Coeverden de Groot HA, Moore PJ, et al. The relative risks of caesarean section (intrapartum and elective) and vaginal delivery: a detailed analysis to exclude the effects of medical disorders and other acute pre-existing physiological disturbances. Br J Obstet Gynaecol. 1990;97(10):883-92. [pmid: 2223678].
24 Groom K, Brown SP. Caesarean section controversy. The rate of caesarean sections is not the issue. BMJ. 2000;320(7241):1072-3. author reply 1074. [pmid: 10764376].
25 Weber AM, Meyn L. Episiotomy use in the United States, 1979-1997. Obstet Gynecol. 2002;100:1177-82. [pmid: 12468160].
26 Kozak LJ, Owings MF, Hall MJ. National Hospital Discharge Survey: 2001 annual summary with detailed diagnosis and procedure data. Vital Health Stat 13 2004;(156):1–198.
27 Fisler RE, Cohen A, Ringer SA, et al. Neonatal outcome after trial of labor compared with elective repeat cesarean section. Birth. 2003;30(2):83-8. [pmid: 12752164].
28 van Ham MA, van Dongen PW, Mulder J. Maternal consequences of caesarean section. A retrospective study of intra-operative and postoperative maternal complications of caesarean section during a 10-year period. Eur J Obstet Gynecol Reprod Biol. 1997;74(1):1-6. [pmid: 9243191].
29 Barros FC, Vaughan JP, Victoria CG. Why so many caesarean sections? The need for a further policy change in Brazil. Health Policy Plan. 1986;1(1):19-29. [pmid: 10283013].
30 Belizan JM, Althabe F, Barros FC, et al. Rates and implications of caesarean sections in Latin America: ecological study. Br Med J. 1999;319(7222):1397-400. [pmid: 10574855]. [pmcid: 28283].
31 Faiz AS, Ananth CV. Etiology and risk factors for placenta previa: an overview and meta-analysis of observational studies. J Matern Fetal Neonatal Med. 2003;13(3):175-90. [pmid: 12820840].
32 Trial of Labor After Cesarean (TOLAC) Policy Team. Trial of labor after cesarean (TOLAC), formerly trial of labor versus elective repeat cesarean section for the woman with a previous cesarean section. A review of the evidence and recommendations by the American Academy of Family Physicians. The American Academy of Family Physicians; 2005.
33 Wilkinson C, McIlwaine G, Boulton-Jones C, et al. Is a rising caesarean section rate inevitable?. Br J Obstet Gynaecol. 1998;105(1):45-52. [pmid: 9442161].
34 Read AW, Waddell VP, Prendiville WJ, et al. Trends in caesarean section in Western Australia, 1980-1987. Med J Aust. 1990;153(6):318-23. [pmid: 2233449].
35 Foley ME, Alarab M, Daly L, et al. Term neonatal asphyxial seizures and peripartum deaths: lack of correlation with a rising cesarean delivery rate. Am J Obstet Gynecol. 2005;192(1):102-8. [pmid: 15672010].
36 Vangen S, Stoltenberg C, Skrondal A, et al. Cesarean section among immigrants in Norway. Acta Obstet Gynecol Scand. 2000;79(7):553-8. [pmid: 10929954].
37 Badawi N, Kurinczuk JJ, Keogh JM, et al. Intrapartum risk factors for newborn encephalopathy: the Western Australian case-control study. Br Med J. 1998;317(7172):1554-8. [pmid: 9836653]. [pmcid: 28733].
38 Bergholt T, Stenderup JK, Vedsted-Jakobsen A, et al. Intraoperative surgical complication during cesarean section: an observational study of the incidence and risk factors. Acta Obstet Gynecol Scand. 2003;82(3):251-6. [pmid: 12694122].
39 Burrows LJ, Meyn LA, Weber AM. Maternal morbidity associated with vaginal versus cesarean delivery. Obstet Gynecol. 2004;103(5 Pt 1):907-12. [pmid: 15121564].
40 Dessole S, Cosmi E, Balata A, et al. Accidental fetal lacerations during cesarean delivery: experience in an Italian level III university hospital. Am J Obstet Gynecol. 2004;191(5):1673-7. [pmid: 15547541].
41 Farrell S, Allen V, Baskett T. Parturition and urinary incontinence in primiparas. Obstet Gynecol. 2001;97(3):350-6. [pmid: 11239635].
42 Farrell SA, Allen VM, Baskett TF. Anal incontinence in primiparas. J Soc Obstet Gynaecol Can. 2001;23(4):321-6.
43 Fawcett J, Pollio N, Tully A. Women's perceptions of cesarean and vaginal delivery: another look. Res Nurs Health. 1992;15(6):439-46. [pmid: 1448575].
44 Groutz A, Rimon E, Peled S, et al. Cesarean section: does it really prevent the development of postpartum stress urinary incontinence? A prospective study of 363 women one year after their first delivery. Neurourol Urodyn. 2004;23(1):2-6. [pmid: 14694448].
45 Hillan EM. Postoperative morbidity following Caesarean delivery. J Adv Nurs. 1995;22(6):1035-42. [pmid: 8675855].
46 Lal M, Mann CH, Callender R, et al. Does cesarean delivery prevent anal incontinence?. Obstet Gynecol. 2003;101(2):305-12. [pmid: 12576254].
47 Levine EM, Ghai V, Barton JJ, et al. Mode of delivery and risk of respiratory diseases in newborns. Obstet Gynecol. 2001;97(3):439-42. [pmid: 11239653].
48 Morrison JJ, Rennie JM, Milton PJ. Neonatal respiratory morbidity and mode of delivery at term: influence of timing of elective caesarean section. Br J Obstet Gynaecol. 1995;102(2):101-6. [pmid: 7756199].
49 Nice C, Feeney A, Godwin P, et al. A prospective audit of wound infection rates after caesarean section in five West Yorkshire hospitals. J Hosp Infect. 1996;33(1):55-61. [pmid: 8738202].
50 Sanchez-Ramos L, Wells TL, Adair CD, et al. Route of breech delivery and maternal and neonatal outcomes. Int J Gynaecol Obstet. 2001;73(1):7-14. [pmid: 11336715].
51 Schindl M, Birner P, Reingrabner M, et al. Elective cesarean section vs. spontaneous delivery: a comparative study of birth experience. Acta Obstet Gynecol Scand. 2003;82(9):834-40. [pmid: 12911445].
52 Zanardo V, Simbi KA, Vedovato S, et al. The influence of timing of elective cesarean section on neonatal resuscitation risk. Pediatr Crit Care Med. 2004;5(6):566-70. [pmid: 15530194].
53 Zanardo V, Simbi AK, Franzoi M, et al. Neonatal respiratory morbidity risk and mode of delivery at term: influence of timing of elective caesarean delivery. Acta Paediatr. 2004;93(5):643-7. [pmid: 15174788].
54 Myles TD, Gooch J, Santolaya J. Obesity as an independent risk factor for infectious morbidity in patients who undergo cesarean delivery. Obstet Gynecol. 2002;100(5 Pt 1):959-64. [pmid: 12423861].
55 van den Berg A, van Elburg RM, van Geijn HP, et al. Neonatal respiratory morbidity following elective caesarean section in term infants. A 5-year retrospective study and a review of the literature. Eur J Obstet Gynecol Reprod Biol. 2001;98(1):9-13. [pmid: 11516792].
56 Gregory KD, Korst LM, Platt LD. Variation in elective primary cesarean delivery by patient and hospital factors. Am J Obstet Gynecol. 2001;184(7):1521-32. discussion 1531–4. [pmid: 11408876].
57 Roberts CL, Taylor L, Henderson-Smart D. Trends in births at and beyond term: evidence of a change?. Br J Obstet Gynaecol. 1999;106(9):937-42. [pmid: 10492105].
58 Roberts CL, Algert CS, Douglas I, et al. Trends in labour and birth interventions among low-risk women in New South Wales. Aust N Z J Obstet Gynaecol. 2002;42(2):176-81. [pmid: 12069146].
59 Farah N, Geary M, Connolly G, et al. The caesarean section rate in the Republic of Ireland in 1998. Ir Med J. 2003;96(8):242-3. [pmid: 14653377].
60 Barley K, Aylin P, Bottle A, et al. Social class and elective caesareans in the English NHS. Br Med J. 2004;328(7453):1399. [pmid: 15191977]. [pmcid: 421774].
61 Khor LJ, Jeskins G, Cooper GM, et al. National obstetric anaesthetic practice in the UK 1997/1998. Anaesthesia. 2000;55(12):1168-72. [pmid: 11121925].
62 Jarvelin MR, Hartikainen-Sorri AL, Rantakallio P. Labour induction policy in hospitals of different levels of specialisation. Br J Obstet Gynaecol. 1993;100(4):310-5. [pmid: 8494831].
63 Lidegaard O, Jensen LM, Weber T. Technology use, cesarean section rates, and perinatal mortality at Danish maternity wards. Acta Obstet Gynecol Scand. 1994;73(3):240-5. [pmid: 8122506].
64 Allen VM, O'Connell CM, Liston RM, et al. Maternal morbidity associated with cesarean delivery without labor compared with spontaneous onset of labor at term. Obstet Gynecol. 2003;102(3):477-82. [pmid: 12962927].
65 Dani C, Reali MF, Bertini G, et al. Risk factors for the development of respiratory distress syndrome and transient tachypnoea in newborn infants. Italian Group of Neonatal Pneumology. Eur Respir J. 1999;14(1):155-9. [pmid: 10489844].
66 Durik AM, Hyde JS, Clark R. Sequelae of cesarean and vaginal deliveries: psychosocial outcomes for mothers and infants. Dev Psychol. 2000;36(2):251-60. [pmid: 10749082].
67 Golfier F, Vaudoyer F, Ecochard R, et al. Planned vaginal delivery versus elective caesarean section in singleton term breech presentation: a study of 1116 cases. Eur J Obstet Gynecol Reprod Biol. 2001;98(2):186-92. [pmid: 11574129].
68 Irion O, Hirsbrunner Almagbaly P, Morabia A. Planned vaginal delivery versus elective caesarean section: a study of 705 singleton term breech presentations. Br J Obstet Gynaecol. 1998;105(7):710-7. [pmid: 9692410].
69 Koroukian SM. Relative risk of postpartum complications in the Ohio Medicaid population: vaginal versus cesarean delivery. Med Care Res Rev. 2004;61(2):203-24. [pmid: 15155052].
70 Krebs L, Langhoff-Roos J. Elective cesarean delivery for term breech. Obstet Gynecol. 2003;101(4):690-6. [pmid: 12681872].
71 MacArthur C, Bick DE, Keighley MR. Faecal incontinence after childbirth. Br J Obstet Gynaecol. 1997;104(1):46-50. [pmid: 8988696].
72 MacArthur C, Glazener CM, Wilson PD, et al. Obstetric practice and faecal incontinence three months after delivery. BJOG. 2001;108(7):678-83. [pmid: 11467690].
73 Mason L, Glenn S, Walton I, et al. The prevalence of stress incontinence during pregnancy and following delivery. Midwifery. 1999;15(2):120-8. [pmid: 10703415].
74 Persson J, Wolner-Hanssen P, Rydhstroem H. Obstetric risk factors for stress urinary incontinence: a population-based study. Obstet Gynecol. 2000;96(3):440-5. [pmid: 10960639].
75 Phipps MG, Watabe B, Clemons JL, et al. Risk factors for bladder injury during cesarean delivery. Obstet Gynecol. 2005;105(1):156-60. [pmid: 15625157].
76 Reichert JA, Baron M, Fawcett J. Changes in attitudes toward cesarean birth. J Obstet Gynecol Neonatal Nurs. 1993;22(2):159-67.
77 Rubaltelli FF, Bonafe L, Tangucci M, et al. Epidemiology of neonatal acute respiratory disorders. A multicenter study on incidence and fatality rates of neonatal acute respiratory disorders according to gestational age, maternal age, pregnancy complications and type of delivery. Italian Group of Neonatal Pneumology. Biol Neonate. 1998;74(1):7-15. [pmid: 9657664].
78 Ryding EL, Wijma K, Wijma B. Psychological impact of emergency cesarean section in comparison with elective cesarean section, instrumental and normal vaginal delivery. J Psychosom Obstet Gynaecol. 1998;19(3):135-44. [pmid: 9844844].
79 Schytt E, Lindmark G, Waldenstrom U. Symptoms of stress incontinence 1 year after childbirth: prevalence and predictors in a national Swedish sample. Acta Obstet Gynecol Scand. 2004;83(10):928-36. [pmid: 15453888].
80 Sutton L, Sayer GP, Bajuk B, et al. Do very sick neonates born at term have antenatal risks? 2. Infants ventilated primarily for lung disease. Acta Obstet Gynecol Scand. 2001;80(10):917-25. [pmid: 11580736].
81 Towner D, Castro MA, Eby-Wilkens E, et al. Effect of mode of delivery in nulliparous women on neonatal intracranial injury. N Engl J Med. 1999;341(23):1709-14. [pmid: 10580069].
82 Wilson PD, Herbison RM, Herbison GP. Obstetric practice and the prevalence of urinary incontinence three months after delivery. Br J Obstet Gynaecol. 1996;103(2):154-61. [pmid: 8616133].
83 Hannah ME, Whyte H, Hannah WJ, et al. Maternal outcomes at 2 years after planned cesarean section versus planned vaginal birth for breech presentation at term: the international randomized Term Breech Trial. Am J Obstet Gynecol. 2004;191(3):917-27. [pmid: 15467565].
84 Leiberman JR, Fraser D, Mazor M, et al. Breech presentation and cesarean section in term nulliparous women. Eur J Obstet Gynecol Reprod Biol. 1995;61(2):111-5. [pmid: 7556830].
85 West SL, King V, Carey TS et al. Systems to Rate the Strength of Scientific Evidence. Evidence Report, Technology Assessment No. 47. Rockville, Md.: Agency for Healthcare Research and Quality. AHRQ Publication No. 02-E016;2002.
86 Government Statistical Service for the Department of Health. NHS maternity statistics, England 2003-04. March 31, 2005 [Web Page]. Available at http://www.dh.gov.uk/assetRoot/04/11/56/03/04115603.xls. (Accessed 10 January 2006).
87 Riley, M, King, J. Births in Victoria 2001-2002, Victorian Perinatal Data Collection Unit, Public Health, Victorian Government Department of Human Services, December 2003, Melbourne, Victoria. [Web Page]. 2003; Available at http://www.health.vic.gov.au/perinatal/pubs.htm. (Accessed 10 January 2006).
88 Riley M, Halliday J. Births in Victoria 1996-1998 [Web Page]. 1999; Available at http://www.health.vic.gov.au/perinatal/pubs.htm. (Accessed 10 January 2006).
89 Riley M, Halliday J. Births in Victoria 1992-1996 [Web Page]. 1998; Available at http://www.health.vic.gov.au/perinatal/pubs.htm. (Accessed 10 January 2006).
90 Chan, A, Nguyen, J, Anh-Mingh, Sage, L. Pregnancy Outcome in South Australia. Pregnancy Outcome Unit, Epidemiology Branch, Department of Health. Adelaide, Australia. June 2005 [Web Page]. 2005; Available at http://www.dh.sa.gov.au/pehs/PDF-files/POU-annual-report03.pdf. (Accessed 10 January 2006).
91 Centre for Epidemiology and Research, NSW Department of Health. New South Wales. Mothers and Babies 2001. N S W Public Health Bull 2002;13(S-4).
92 Riley M, Halliday J. Births in Victoria 1999-2000 [Web Page]. 2001; Available at http://www.health.vic.gov.au/perinatal/pubs.htm. (Accessed 10 January 2006).
93 Zerssen D, von Koeller D, Rey E. Die Befindlichkeits-Skala (B-S) ein einfaches Instrument zur Objektivierungvon Befindlichkeits-St örungen, insbesondere im Rahmen von Längsschnitt-Untersuchungen. Arzneimittel-Forsch. 1970;20:915-18. [pmid: 5536059].
94 Salmon P, Drew NC. Multidimensional assessment of women's experience of childbirth: relationship to obstetric procedure, antenatal preparation and obstetric history. J Psychosom Res. 1992;36(4):317-27. [pmid: 1593507].
95 Cranley MS, Hedahl KJ, Pegg SH. Women's perceptions of vaginal and cesarean deliveries. Nurs Res. 1983;32(1):10-5. [pmid: 6549836].
96 Guise J, et al. Vaginal Birth After Cesarean (VBAC). 2003.
97 McMahon MJ, Luther ER, Bowes WA Jr, et al. Comparison of a trial of labor with an elective second cesarean section. N Engl J Med. 1996;335(10):689-95. [pmid: 8703167].
98 Dashe JS, McIntire DD, Ramus RM, Santos-Ramos R, Twickler DM. Persistence of placenta previa according to gestational age at ultrasound detection. Obstet Gynecol. 2002;99(5 Pt 1):692-7. [pmid: 11978274].
99 Crane JM, Van den Hof MC, Dodds L, Armson BA, Liston R. Maternal complications with placenta previa. Am J Perinatol. 2000;17(2):101-5. [pmid: 11023169].
100 Lydon-Rochelle M, Holt VL, Easterling TR, Martin DP. First-birth cesarean and placental abruption or previa at second birth(1). Obstet Gynecol. 2001;97(5 Pt 1):765-9. [pmid: 11339931].
101 Sheiner E, Shoham-Vardi I, Hallak M, Hershkowitz R, Katz M, Mazor M. Placenta previa: obstetric risk factors and pregnancy outcome. J Matern Fetal Med. 2001;10(6):414-9. [pmid: 11798453].
102 Rasmussen S, Albrechtsen S, Dalaker K. Obstetric history and the risk of placenta previa. Acta Obstet Gynecol Scand. 2000;79(6):502-7. [pmid: 10857876].
103 Hossain GA, Islam SM, Mahmood S, Chakraborty RK, Akhter N, Sultana S. Placenta previa and it's relation with maternal age, gravidity and cesarean section. Mymensingh Med J. 2004;13(2):143-8. [pmid: 15284689].
104 Makoha FW, Felimban HM, Fathuddien MA, Roomi F, Ghabra T. Multiple cesarean section morbidity. Int J Gynaecol Obstet. 2004;87(3):227-32. [pmid: 15548394].
105 Gilliam M, Rosenberg D, Davis F. The likelihood of placenta previa with greater number of cesarean deliveries and higher parity. Obstet Gynecol. 2002;99(6):976-80. [pmid: 12052584].
106 Eniola AO, Bako AU, Selo-Ojeme DO. Risk factors for placenta praevia in southern Nigeria. East Afr Med J. 2002;79(10):535-8. [pmid: 12635759].
107 Johnson LG, Mueller BA, Daling JR. The relationship of placenta previa and history of induced abortion. Int J Gynaecol Obstet. 2003;81(2):191-8. [pmid: 12706277].
108 Tuzovic L, Djelmis J, Ilijic M. Obstetric risk factors associated with placenta previa development: case-control study. Croat Med J. 2003;44(6):728-33. [pmid: 14652887].
109 Laughon SK, Wolfe HM, Visco AG. Prior cesarean and the risk for placenta previa on second-trimester ultrasonography. Obstet Gynecol. 2005;105(5 Pt 1):962-5. [pmid: 15863531].
110 Francois K, Johnson JM, Harris C. Is placenta previa more common in multiple gestations?. Am J Obstet Gynecol. 2003;188(5):1226-7. [pmid: 12748486].
111 Graziosi GC, Bakker CM, Brouwers HA, et al. [Elective cesarean section is preferred after the completion of a minimum of 38 weeks of pregnancy]. Ned Tijdschr Geneeskd. 1998;142(42):2300-3. [pmid: 9864525].
112 Johnston T, Coory M. Cesarean Section Deliveries in Queensland. Information Circular 2005.
113 Hall MH, Bewley S. Maternal mortality and mode of delivery. Lancet. 1999;354(9180):776. [pmid: 10475219].
114 Why mothers die. Report on confidential enquiries into maternal deaths in the United Kingdom 1994-96. London: Stationery Office; 1998.
115 National Vital Statistics. National vital statistics report deaths: final data for 2003 [Web Page]. Available at http://www.cdc.gov/nchs/products/pubs/pubd/hestats/finaldeaths03/finaldeaths03.htm. (Accessed 27 January 2006).
116 Viswanathan M, Hartmann K, Palmieri R et al. The Use of Episiotomy in Obstetrical Care: A Systematic Review. Evidence Report/Technology Assessment No. 112. Prepared by the RTI-UNC Evidence-based Practice Center, under Contract No. 290-02-0016. AHRQ Publication No. 05-E009-2. Rockville, MD: Agency for Healthcare Research and Quality.;2005.
117 Beckmann M, Garrett A. Antenatal perineal massage for reducing perineal trauma. Cochrane Database Syst Rev 2006;(1):CD005123.
118 DiMatteo MR, Morton SC, Lepper HS, et al. Cesarean childbirth and psychosocial outcomes: a meta-analysis. Health Psychol. 1996;15(4):303-14. [pmid: 8818678].
119 Buchsbaum GM, Chin M, Glantz C, et al. Prevalence of urinary incontinence and associated risk factors in a cohort of nuns. Obstet Gynecol. 2002;100(2):226-9. [pmid: 12151141].
120 Goldberg RP, Abramov Y, Botros S, et al. Delivery mode is a major environmental determinant of stress urinary incontinence: results of the Evanston-Northwestern Twin Sisters Study. Am J Obstet Gynecol. 2005;193(6):2149-53. [pmid: 16325632].
121 Hemminki E. Impact of caesarean section on future pregnancy—a review of cohort studies. Paediatr Perinat Epidemiol. 1996;10(4):366-79. [pmid: 8931052].
122 Martin J, et al. Vaginal delivery following previous cesarean birth. Am J Obstet Gynecol. 1983;146(3):255-63. [pmid: 6859134].
123 Landon MB, Hauth JC, Leveno KJ, et al. Maternal and perinatal outcomes associated with a trial of labor after prior cesarean delivery. N Engl J Med. 2004;351(25):2581-9. [pmid: 15598960].
124 Smith GC, Pell JP, Dobbie R. Caesarean section and risk of unexplained stillbirth in subsequent pregnancy. Lancet. 2003;362(9398):1779-84. [pmid: 14654315].
125 Hilder L, Costeloe K, Thilaganathan B. Prolonged pregnancy: evaluating gestation-specific risks of fetal and infant mortality. Br J Obstet Gynaecol. 1998;105(2):169-73. [pmid: 9501781].
126 Manson JE, Hsia J, Johnson KC, et al. Estrogen plus progestin and the risk of coronary heart disease. N Engl J Med. 2003;349(6):523-34. [pmid: 12904517].
127 Anderson GL, Limacher M, Assaf AR, et al. Effects of conjugated equine estrogen in postmenopausal women with hysterectomy: the Women's Health Initiative randomized controlled trial. J Am Med Assoc. 2004;291(14):1701-12.
128 Moseley JB, O'Malley K, Petersen NJ, et al. A controlled trial of arthroscopic surgery for osteoarthritis of the knee. N Engl J Med. 2002;347(2):81-8. [pmid: 12110735].
129 Guyatt GH, Haynes RB, Jaeschke RZ, et al. Users guide to the medical literature: XXV. Evidence-based medicine: principles for applying the users' guides to patient care. J Am Med Assoc. 2000;284:1291.
130 Pelvic Floor Disorders Network. What is pelvic floor disorder [Web Page]. 2005; Available at http://www.pfdn.org/what/index.html#prolapse. (Accessed 6 January 1912)