# Executive Summary

## Introduction

The RTI International-University of North Carolina at Chapel Hill Evidence-based Practice Center (RTI-UNC EPC) conducted this systematic evidence review on cesarean delivery on maternal request (CDMR) for the Agency for Healthcare Research and Quality (AHRQ). This review summarizes the available literature, frames the discussions regarding benefits and harms for an upcoming State of the Science (SOS) Conference organized by the National Institutes of Health (NIH), Office of Medical Applications of Research (OMAR), and highlights the limitations of the evidence base. We received advice and input from an independent Technical Expert Panel (TEP).

For this review, we defined CDMR as a cesarean delivery for a singleton pregnancy, on maternal request, at term, and in the absence of any maternal or fetal indication for cesarean delivery. We recognized that the available literature does not explicitly define CDMR as a specific study group to allow for comparison with other planned routes of delivery. Given this lack of evidence on CDMR per se, the SOS conference planning committee requested that we include proxies for CDMR such as cesarean deliveries for breech presentation.

We also recognized that the ideal comparison groups to address the potential benefits and harms of CDMR would be planned vaginal delivery and planned CDMR in a low-risk population. Planned vaginal delivery does not always result in spontaneous labor followed by spontaneous vaginal delivery. Therefore, the ideal evidence demands a comparison of intent: planned vaginal delivery with planned CDMR rather than the comparison of actual delivery routes such as spontaneous vaginal delivery with unlabored cesarean. In the absence of such high-quality evidence, we compiled a summary of the best available literature, using proxies for CDMR, frequently relying on studies that define groups by actual route of delivery and not planned route of delivery.

We systematically reviewed the evidence on three key questions (KQs): (1) trend and incidence of cesarean delivery over time, (2) effect of approach to delivery (CDMR compared with planned vaginal delivery) on maternal and neonatal outcomes, and (3) factors that affect the magnitude of the benefits and harms identified in KQ2. Additionally, we described future research directions as KQ4.

Several factors make interpretation of the available evidence challenging: (1) comparisons are generally made by actual, not planned, routes of delivery (the latter being a preferred intent-to-treat approach); (2) available proxies are of variable relevance to CDMR; (3) practice patterns vary widely over time and among providers, (4) confounders are common and rarely accounted for; (5) statistical power is frequently inadequate, particularly for rare outcomes; (6) timing of outcomes and their measurement is inappropriate; (7) investigators use unvalidated questionnaires; and (8) severity and utility ratings of various outcomes are typically lacking.

## Methods

We searched MEDLINE^®^, Cochrane Collaboration resources, and Embase. Based on key questions and discussion with our TEP, we generated a list of article inclusion and exclusion criteria. We excluded studies that: (1) did not report on women of reproductive age; (2) were published in languages other than English; (3) did not report information pertinent to the key clinical questions; (4) had fewer than 50 subjects for randomized controlled trials (RCTs) or 100 subjects for observational studies; and (5) were not original studies. Additionally, and in consultation with the TEP, we excluded studies that did not provide data on both planned cesarean delivery and planned vaginal delivery for KQ 1 and KQ 2. As a consequence of this search strategy, we cannot address outcomes or modifiers unique to vaginal delivery, without reference to a cesarean delivery comparison group. Our aim was to compare primary planned cesarean delivery (cesarean delivery on maternal request, or CDMR) with planned vaginal delivery. Time and resources did not permit us to review comprehensively the benefits and harms associated with repeat cesarean deliveries. However, we did summarize outcomes particularly relevant to subsequent cesarean deliveries such as subsequent uterine rupture, subsequent fertility, and placenta previa by examining recent systematic reviews or updating a recent meta-analysis.

We reviewed each abstract and article systematically against a priori criteria to determine inclusion in the review. Two reviewers separately evaluated the abstracts for inclusion or exclusion. If one abstractor concluded that the article should be included in the review, we retained it. We assigned each excluded article a reason for exclusion. We entered the data from abstraction forms into evidence tables and checked for consistency and accuracy. Staff reconciled all disagreements about information in evidence tables.

The vast majority of studies reported results on actual route of delivery rather than planned route of delivery (intent to treat). The comparison groups varied widely. We found it impossible to arrive at any meaningful summary of the literature without explicitly categorizing the comparison groups and the studies themselves. We developed a four-tier classification system of relevance to CDMR based on the following criteria: (1) whether studies analyzed outcomes by planned route of delivery (trials of route of delivery); (2) whether CDMR was included as a comparison group (high relevance); (3) whether comparison groups comprised planned cesareans (moderate relevance), and (4) whether studies involved undefined “elective” or a mix of planned and unplanned, unlabored cesareans (low relevance).

We rated trials of routes of delivery and studies of high and moderate relevance for quality, assigning scores of good, fair, or poor. For RCTs, our rating system evaluated (1) randomization approach and implementation; (2) post-randomization exclusion; (3) masking; (4) operational definitions and measurements; (5) loss to followup; and (6) statistical analysis. For nonrandomized observational cohorts, we evaluated (1) study design; (2) study population; (3) comparability of subjects; (4) statistical analysis; (5) measure of effect and loss to followup. We summarized the strength of evidence for each outcome, judging the evidence to be strong for results that are clinically important, consistent, and free from serious doubts about generalizability, bias, or flaws in research design. We judged evidence to be moderate for studies of strong design, with some inconsistencies or concern about generalizability, bias, research design flaws or for studies of weaker design with consistent evidence. We judged evidence to be weak for studies of weaker design with inconsistent results or studies of strong design with inconclusive results.

From our review of 1,406 abstracts, we found 69 articles comprising 65 studies that addressed one or more key questions. Of these, 13 addressed KQ1, 54 addressed KQ2, and 5 addressed KQ3.

## Results

### KQ1: Incidence and Trends of Cesarean Delivery on Maternal Request

KQ 1 referred to the incidence and trends in cesarean deliveries over time in developed countries; it made specific reference to primary cesarean before onset of labor, CDMR, medical indications, and malpresentation as proportions of total cesarean deliveries. The absence of data to answer this question is striking. Regarding incidence, the available literature yielded rates of cesarean deliveries as a proportion of all deliveries for a wide array of time points and countries. For 2001 in the United States, data suggest rates of more than 25 percent. Elsewhere in the developed world for 2001, rates of cesarean delivery ranged from 14 percent in The Netherlands to 35 percent in Italy. Since 2001, the rates of cesarean delivery have risen in the United States; recent figures put the rate at more than 29 percent for 2004.

The rate of cesarean deliveries is rising worldwide. Both “elective” cesarean deliveries (sometimes defined as unlabored) and “nonelective” cesarean deliveries contribute to this rise; however, the proportions vary by country, study, and time period. Four studies distinguished between prelabor primary and repeat cesareans. An Irish study reported an unlabored primary cesarean delivery rate of 18.9 percent of all cesarean deliveries during the 12-year period from 1989 to 2000. One study in Australia showed that prelabor primary cesarean delivery as a percentage of all deliveries rose from 4.1 percent in 1980 to 4.8 percent in 1987. In the United States, primary prelabor cesarean delivery rates were approximately 5 percent of all deliveries in 1996 and approximately 7 percent in 2001. In 2001, “primary elective” prelabor cesarean rate as a proportion of all cesarean deliveries was 28.3 percent in the United States.

The extent to which CDMR is contributing to the rise in cesareans remains unclear. Finally, we did not find sufficient data to comment on medical indications or malpresentation as a proportion of all cesarean deliveries.

### KQ 2: Outcomes of Cesarean Delivery on Maternal Request

Overall, few moderately relevant studies were available, and the strength of evidence is weak for nearly all outcomes.

Maternal outcomes for primary cesarean deliveries. Mortality. Four studies suggested no evidence of difference in maternal mortality associated with planned vaginal versus planned cesarean delivery. These studies provided weak evidence overall.

Infection. The 12 studies that included maternal infection as an outcome provided weak evidence that the risk of maternal infection was lower with planned cesarean than with unplanned cesarean delivery and lower for vaginal than for cesarean delivery.

Anesthetic complications. Two studies showed a lower rate of anesthetic complications with planned vaginal than with planned cesarean delivery; the third reported no significant difference between these two routes of delivery. These studies provided weak evidence suggesting a lower rate of anesthetic complications with planned vaginal delivery.

Hemorrhage and blood transfusion. Eleven studies provided moderate strength of evidence showing a lower risk of hemorrhage and blood transfusion in planned cesareans than in vaginal delivery. These studies also yielded evidence of lower hemorrhage or blood transfusion in planned cesareans than in unplanned cesareans.

Hysterectomy. Three studies yielded weak evidence on the association between emergency hysterectomy after childbirth and either planned vaginal or planned cesarean delivery. The rarity of the outcome results in insufficient statistical power to draw firm conclusions regarding the risk associated with either delivery route.

Thromboembolism. Eight studies provided weak evidence for an association between thromboembolism and planned vaginal or planned cesarean delivery. Studies reported no consistent direction or magnitude of effect.

Surgical complications. Ten studies provided weak evidence on surgical complications associated with planned vaginal and planned cesarean delivery. Studies generally showed a lower risk of surgical complications in planned “elective” cesarean than unplanned “emergency” or “labored” cesarean deliveries.

Breastfeeding. One study provided weak evidence that although women with planned vaginal deliveries may initiate breastfeeding sooner than women with planned cesarean deliveries, they do not report any difference in the duration of breastfeeding. Other evidence suggests that women are more likely to bottlefeed following a cesarean delivery (planned or unplanned) compared with a vaginal delivery.

Postpartum pain. Four articles (from three studies) reported on postpartum pain using various pain measures at different time periods. Together, these studies provide weak evidence of no significant difference in pain between modes of delivery, but they draw from populations with breech deliveries and may, therefore, overestimate the pain in the planned vaginal delivery group.

Psychological outcomes: postpartum depression. Two studies provide weak evidence suggesting no differences in postpartum depression by delivery route. As with pain, studies with breech populations likely overestimated the rate of complications, interventions, and possible negative psychological outcomes in the planned vaginal delivery group.

Psychological outcomes: other. Seven articles (from six studies) yielded weak evidence about a range of other psychological outcomes. The data were consistent in reporting that women who had an unplanned cesarean birth or an instrumental vaginal delivery were more likely to experience adverse psychological outcomes than were women who either underwent a spontaneous vaginal or a planned cesarean birth. The variety of outcomes and measures makes a summative assessment of other outcomes challenging.

Maternal length of stay. Four studies provided moderate evidence that length of stay is higher for cesarean delivery, planned or otherwise, than for vaginal delivery.

Urinary incontinence. Nine articles (from eight studies) provided weak evidence that rates of stress urinary incontinence for planned “elective” cesarean section were either lower than or no different from those for vaginal delivery. Numerous problems limit evidence on this outcome: lack of high-quality prospective studies that compare planned routes of delivery, have adequate power, include comprehensive long-term followup, account for multiple deliveries, account for variations in practice patterns including use of epidural anesthesia and episiotomy, use validated urinary questionnaires administered at consistent time points from delivery, and define incontinence in a standardized fashion by its occurrence, severity, and impact on quality of life.

Anorectal function. Seven articles (from six studies) provided weak evidence showing a reduced risk of anal incontinence in planned cesarean deliveries compared with unplanned cesarean or instrumental vaginal deliveries. Evidence was inconsistent about differences between planned cesarean and spontaneous vaginal delivery.

Pelvic organ prolapse. We found no evidence on the association between pelvic organ prolapse and planned vaginal or planned cesarean delivery.

Sexual function. One study provided weak evidence that sexual function does not differ by planned route of delivery.

Maternal outcomes relevant to subsequent cesarean delivery. Subsequent fertility issues. Studies not included in this review suggests a higher risk with all cesarean deliveries (unplanned or planned), but we found no reliable evidence of difference relevant to CDMR.

Subsequent uterine rupture. A recent update of a systematic review on the outcomes of vaginal birth after cesarean (VBAC) provided moderate evidence on subsequent uterine rupture. The update found no statistically significant differences between trial of labor after cesarean and elective repeat cesarean delivery with regard to rates of asymptomatic uterine rupture rates. The update noted that two studies of fair or good quality found a small but higher risk of symptomatic uterine rupture in trial of labor after cesarean than in elective repeat cesarean delivery.

Placenta previa. Given that placenta previa is the most common placental implantation anomaly, we updated a recent meta-analysis examining the relationship between placenta previa and a history of cesarean delivery. Our update supports the earlier meta-analytic conclusion that the odds of placenta previa are associated with advancing maternal age and increasing parity. The literature provided moderate evidence that the risk of placenta previa increases with previous cesarean delivery.

Subsequent stillbirth. Studies not included in this review suggest a higher risk with all cesarean deliveries (unplanned or planned), but we found no reliable evidence of difference relevant to CDMR.

Neonatal outcomes. Fetal mortality. We found no studies that addressed fetal (in utero) deaths.

Neonatal mortality. Two studies provided weak evidence on neonatal mortality. The studies suggested a higher risk for all cesareans (planned or unplanned) than for spontaneous vaginal delivery. The studies did not control for underlying maternal or neonatal indications for cesarean or were underpowered for such a rare outcome, leading to limited ability to draw conclusions on this outcome.

Unexpected (iatrogenic) prematurity. We found no study that addressed unexpected prematurity and allowed comparisons by type of cesarean with intended or actual vaginal birth.

Respiratory morbidity. Measures of respiratory morbidity range from transient tachypnea of the newborn (TTN) to severe respiratory distress syndrome (RDS) with long-term sequelae. Nine articles yielded moderate evidence that the risk of variably defined “respiratory morbidity” was higher for all cesarean births than for vaginal deliveries. This risk reduces with advancing gestational age. Studies did not assess meconium aspiration syndrome by mode of delivery.

Transition issues. One study reported on this outcome, but the significant issues of appropriate categorization in this study make interpreting the data difficult. We consider the available evidence insufficient to judge the direction of effect.

Neonatal asphyxia or encephalopathy. Two studies provided weak evidence of a higher risk of neonatal encephalopathy associated with operative vaginal deliveries and “emergency” or “labored” cesareans than with spontaneous vaginal delivery.

Intracranial hemorrhage. One study provided weak evidence on intracranial (subdural/cerebral, intraventricular, and subarachnoid) hemorrhage. The prelabor cesarean deliveries included those done for maternal or neonatal indications, so they likely involved cesareans for placenta previa and fetal anomalies, which may independently increase the risk of intracranial hemorrhage. Despite the higher theoretical risk for prelabor cesarean deliveries, this study did not find any significant difference between spontaneous vaginal delivery and prelabor cesarean deliveries. It did show consistently higher rates of intracranial hemorrhage for assisted vaginal deliveries and cesarean deliveries in labor.

Facial nerve injury. One study provided weak evidence that the risk of facial nerve injury varies by mode of delivery; the risk is higher for forceps and the combined use of forceps and vacuum delivery than for spontaneous vaginal delivery. These findings suggested that CDMR posed no risk for facial nerve injury greater than that associated with planned vaginal delivery.

Brachial plexus injury. One study provides weak evidence that the incidence of brachial plexus injury is lower in cesarean delivery than in vaginal delivery.

Fetal laceration. Two studies provided weak evidence on fetal lacerations based on data limited to cesarean deliveries. They reported a higher rate of fetal lacerations among emergency and labored cesarean than among elective cesarean delivery.

Neonatal length of hospital stay. One study provided weak evidence that the neonatal length of hospital stay is higher for “elective” cesarean delivery than for vaginal delivery.

Long-term neonatal outcomes. We did not find any evidence on long-term neonatal outcomes.

### KQ 3: Modifiers of Cesarean Delivery on Maternal Request

The evidence on effect modifiers is sparse and pertains to only a few outcomes for KQ 2. Five studies provided evidence on the modifiers of CDMR, specifically neonatal respiratory distress, infectious morbidity, and urinary incontinence.

With regard to respiratory morbidity, results showed a consistent decrease in respiratory morbidity as gestational age rises, despite differences in inclusion criteria and definitions of elective cesarean delivery. Gestational age appears to play a lesser role as a risk factor for fetal respiratory distress in planned vaginal delivery than in planned cesarean.

With regard to infectious morbidity, the single study we found suggested no effect of physician experience, incision type, maternal age, or prophylactic antibiotics on infectious morbidity; it did suggest that the risk was higher among obese or black patients than among other women. Pelvic floor exercises decreased the risk of urinary incontinence; pre-pregnancy body mass index increased it.

Given the lack of evidence directly comparing effect modifiers in a population with planned CDMR with those in a population with planned vaginal delivery, inferences about effect modifiers must be drawn cautiously. Furthermore, most studies did not adjust for confounders, so results must be interpreted as crude estimates.

## Conclusions

The incidence of CDMR appears to be increasing. However, accurately assessing its true incidence or trends over time is difficult because currently CDMR is neither a well-recognized clinical entity nor an accurately reported indication for diagnostic coding or reimbursement. More information is available on this question from nations other than the United States, and they differ from this country in health systems, cultural attitudes, patient demographics, and other factors. Drawing inferences from non-US sources, therefore, must be done with caution.

Virtually no studies exist on CDMR per se, so the knowledge base rests chiefly on indirect evidence from proxies such as cesareans performed for breech presentation. These proxies each possess unique and significant limitations. Furthermore, the vast majority of studies to date compared outcomes by actual routes of delivery, not planned routes of delivery. Therefore, significant uncertainty remains regarding the “ideal” route of delivery. Primary CDMR and planned vaginal delivery likely do differ with respect to individual outcomes for either mothers or infants. However, our comprehensive assessment, across many different outcomes, suggests that no major differences exist between primary CDMR and planned vaginal delivery, but the evidence is too weak to conclude definitively that differences are completely absent. If a woman chooses to have a cesarean delivery in her first delivery, she is more likely to have subsequent deliveries by cesarean. With increasing numbers of cesarean delivery, risks occur with increasing frequency.

Given the limited data available, we cannot make definitive conclusions about factors that might influence outcomes of planned CDMR versus planned vaginal delivery. Neither is the knowledge base adequate to comment definitively on many factors that influence the outcomes of actual cesarean and vaginal deliveries.

Our review was focused on primary CDMR. We note that a comprehensive assessment of the risks and benefits of CDMR extends beyond the first cesarean. Future research needs to account for complications and risks associated with repeat cesarean deliveries such as adhesions, placenta previa and accreta, and subsequent stillbirths.

Significant resources will need to be allocated to study CDMR if the nation is to be well informed about the benefits and harms to mothers and infants in both the first and subsequent pregnancies. To realize the maximum gain from such work, research intended to answer questions about maternal and neonatal outcomes of CDMR must study them by intent-to-treat methods. This means comparing outcomes of planned CDMR with those of planned vaginal delivery, not comparing outcomes by actual routes of delivery.

Future research efforts need to focus on a substantial set of problems: developing consensus about terminology for both delivery routes and outcomes; creating a minimum data set of information about CDMR; improving study design and statistical analyses; attending to major outcomes and their special measurement issues; assessing both short- and long-term outcomes with better measurement strategies; dealing better with confounders; and considering the value or utility (in quality-of-life terms) of different outcomes. Examining the costs and cost-effectiveness of different pathways of delivery and considering the impact of CDMR on the medicolegal system also warrant attention.

Finally, if we are to gain meaningful data on short- and long-term maternal and neonatal outcomes associated with CDMR (whether or not compared with planned vaginal delivery), we should define success as a healthy mother and infant in the broadest sense of well-being possible. Studies ought to be well-designed, prospective, and with adequate sample sizes and clearly described power analyses for both common and rare outcomes. Accumulating such high-quality evidence is possible with cooperation from all stakeholders; acquiring it is imperative if women and care providers are to be able to make informed decisions about CDMR.