# Discussion

This chapter first discusses our findings for three key questions (KQ) relating to incidence and trends for cesarean delivery on maternal request (CDMR), maternal and neonatal outcomes of a variety of delivery routes relative to CDMR or proxies for CDMR, and factors that may influence those outcomes. We also address KQ 4, which concerns limitations of the evidence base and our recommendations for future research.

As explained in Chapters 2 and 3, few studies dealt directly with CDMR, so we developed relevance ratings of studies in addition to the typical ratings done with respect to the quality of individual studies. Relevance ratings could be high (essentially nonexistent in this evidence base), moderate, or low; quality ratings, derived from commonly adopted approaches, could be good, fair, or poor. In all, we included 69 articles that pertained to KQ 1, 2, or 3.

We also developed definitions for the strength of the evidence base for these three issues. Chapter 2 provides details; the basic categories are as follows:

I Strong evidence: The evidence is from studies of strong design; results are both clinically important and consistent with minor exceptions at most; results are free from serious doubts about generalizability, bias, or flaws in research design. Studies with negative results have sufficiently large samples to have adequate statistical power.
II Moderate evidence: The evidence is from studies of strong design, but some uncertainty remains because of inconsistencies or concern about generalizability, bias, research design flaws, or adequate sample size. Alternatively, the evidence is consistent but derives from studies of weaker design.
III Weak evidence: The evidence is from a limited number of studies of weaker design. Studies with strong design either have not been done or are inconclusive.
IV No evidence: No published literature.

For KQ 1, one study was of high relevance and remaining studies were of fair or poor quality; thus, information to answer KQ 1 was weak. With respect to KQ 2, generally only weak evidence was available to characterize most maternal and neonatal outcomes involving a comparison of planned CDMR with planned vaginal delivery (KQ 2). Evidence to address the question of modifiers of outcomes of planned CDMR and planned vaginal delivery (KQ 3) was also at best only weak.

## Results

### KQ 1: Incidence and Trends of Cesarean Delivery on Maternal Request

KQ 1 referred to the incidence and trends in cesarean deliveries over time in developed countries; it made specific reference to primary cesarean before onset of labor, CDMR, medical indications, and malpresentation as proportions of total cesarean deliveries. The absence of data to answer this question is striking. Regarding incidence, the available literature yielded rates of cesarean deliveries as a proportion of all deliveries for a wide array of time points and countries. For 2001 in the United States, data suggest rates of more than 25 percent.^3^ Elsewhere in the developed world for 2001, rates of cesarean delivery ranged from 14 percent in the Netherlands to 35 percent in Italy.^112^ Since 2001, the rates of cesarean delivery have risen in the United States; recent figures put the rate at more than 29 percent for 2004.^2^

The rate of cesarean deliveries is rising worldwide. Both “elective” cesarean deliveries (sometimes defined as unlabored) and “nonelective” cesarean deliveries contribute to this rise; however, the proportions vary by country, study, and time period. Four studies distinguished between prelabor primary and repeat cesareans. An Irish study reported an unlabored primary cesarean delivery rate of 18.9 percent of all cesarean deliveries during the 12-year period from 1989 to 2000.^35^ One study in Australia showed that prelabor primary cesarean delivery as a percentage of all deliveries rose from 4.1 percent in 1980 to 4.8 percent in 1987.^34^ In the United States, primary prelabor cesarean delivery rates were approximately 5 percent of all deliveries in 1996^3,^ ^56^ and approximately 7 percent in 2001.^3^ In 2001, “primary elective” prelabor cesarean rate as a proportion of all cesarean deliveries was 28.3 percent in the United States.^3^

The extent to which CDMR is contributing to the rise in cesareans remains unclear. We found a single study addressing CDMR, but its data are more than a decade old and were drawn from a single area (Scotland).^33^ All other studies that we identified either made no attempt to define “elective” cesarean or included such a variety of indications that precluded them from being acceptable proxies for CDMR. Thus, we identified no recent data regarding the rate of CDMR.

A more fundamental problem is that administrative records used to compile such statistics do not contain the details necessary to discern whether the expectant mother desired a vaginal delivery or a cesarean delivery; nor do they provide insight into the decisionmaking process that produced a preference (either the mother's or the clinician's) or who else may have been involved in that process.

Finally, we did not find sufficient data to comment on medical indications or malpresentation as a proportion of all cesarean deliveries.

### KQ 2: Outcomes of Cesarean Delivery on Maternal Request

We discuss below maternal and neonatal outcomes of interest to the State-of-the-Science (SOS) planning committee. Overall, few moderately relevant studies were available, and the strength of evidence is weak (category III) for nearly all outcomes. We summarize the direction of effect and strength of evidence and enumerate the number of trials of planned vaginal delivery to planned cesarean delivery or studies of moderate relevance to CDMR in two tables below: Table 31 (immediately below) deals with maternal outcomes (both primary cesarean and subsequent cesarean deliveries; Table 32 (later) covers neonatal outcomes.

Table 31 Summary of maternal outcomes, directions of effect, and strength of evidence

Maternal Outcome | Direction of Effect | Strength of Evidence
Maternal Outcomes Relevant to Primary Cesarean Deliveries
Maternal mortality | No evidence of difference between cesarean and vaginal delivery (planned or actual) | II
Infection | Lower risk with planned “elective” than labored or emergency cesarean; higher risk with cesarean overall compared with vaginal delivery | III
Anesthetic complications | Lower risk with planned vaginal delivery from limited evidence | III
Hemorrhage/blood transfusion | Lower risk with planned “elective” than vaginal or unplanned cesarean delivery | II
Hysterectomy | No evidence of difference from underpowered studies | II
Thromboembolism | No consistent evidence of direction or magnitude of difference | III
Surgical complications | Lower risk of surgical complications with elective or unlabored cesarean compared with labored or emergency cesarean births, lower risk of perineal trauma with elective cesarean compared with spontaneous vaginal deliveries and assisted vaginal deliveries | III
Breastfeeding | No evidence of difference in the duration of breastfeeding, previous reviews suggest higher risk of bottle feeding compared with breastfeeding for cesareans overall compared with vaginal delivery | III
Postpartum pain | No evidence of difference | III
Psychological outcomes: postpartum depression | No evidence of difference; however, trial of breech presentation likely overestimates challenges, interventions, and resultant negative psychological outcomes in the planned vaginal delivery group | III
Psychological outcomes: other | Lower risk of negative birth experience with planned cesarean or spontaneous vaginal delivery compared with unplanned cesarean or instrumental vaginal delivery, other outcomes too varied to summarize | III
Maternal length of stay | Longer hospital stay with planned and unplanned cesarean compared with vaginal delivery | II
Urinary incontinence | Lower risk with primary elective cesarean than vaginal delivery, protective effect may diminish with increasing age, parity, and BMI | III
Anorectal function | Lower risk with planned cesarean deliveries compared with unplanned cesarean or instrumental vaginal deliveries.Inconsistent evidence of difference between planned cesarean and spontaneous vaginal delivery | III
Pelvic organ prolapse | No evidence | IV
Sexual function | No evidence of difference | III
Maternal Outcomes Relevant to Subsequent Cesarean Deliveries
Subsequent fertility issues | Higher risks with all cesarean, no reliable evidence of difference relevant to CDMR | IV
Subsequent uterine rupture | No difference in asymptomatic uterine rupture, small higher risk of symptomatic rupture with trial of labor compared with elective repeat cesarean | II
Subsequent placenta previa | Higher risk with cesarean, risk increases with advancing maternal age, parity, and number of prior cesareans | II
Subsequent stillbirth | Higher risks with all cesarean, no reliable evidence of difference relevant to CDMR | IV

Table 32 Summary of neonatal outcomes, directions of effect, and strength of evidence

Neonatal Outcomes | Direction of Effect | Strength of Evidence
Fetal mortality | No evidence | IV
Neonatal mortality | Higher risk for “cesarean” than for spontaneous vaginal delivery; no controls for underlying maternal or neonatal indications for cesarean | III
Unexpected (iatrogenic) prematurity | No evidence allows comparison of unlabored cesarean and planned vaginal birth | IV
Respiratory morbidity | Higher risk with cesarean; risk drops with advancing gestational age; no study evaluated meconium aspiration syndrome by mode of delivery | II
Transition | Insufficient evidence to judge direction or magnitude of effect | III
Neonatal asphyxia/ encephalopathy | Inconsistent evidence of risk with elective cesarean; higher risk for operative vaginal deliveries and emergency or labored cesareans than for spontaneous vaginal delivery | III
Intracranial hemorrhage | No difference between prelabor cesarean and spontaneous vaginal delivery; higher risk for assisted vaginal deliveries and cesarean deliveries in labor than for spontaneous vaginal delivery | III
Facial nerve injury | No difference between vacuum or prelabor cesarean delivery and spontaneous vaginal delivery; higher risk for forceps and combined vacuum and forceps than for either a vaginal or cesarean delivery | III
Brachial plexus injury | Lower risk for all cesareans than for spontaneous vaginal delivery; higher risk for vacuum, forceps, and combined vacuum and forceps delivery than for spontaneous vaginal delivery | III
Fetal lacerations | Lower risk for elective cesarean than for unplanned cesarean | III
Neonatal length of stay | Higher risk of longer hospital stay with elective compared with vaginal delivery | III
Long-term outcomes | No evidence | IV

Maternal outcomes for primary cesarean deliveries. Mortality. Four studies^20,^ ^28,^ ^64,^ ^70^ suggested no evidence of difference in maternal mortality associated with planned vaginal versus planned cesarean delivery. These studies provide weak evidence overall. The 2000 report from the International Term Breech Trial (hereafter Breech Trial; which randomized women to planned vaginal vs. planned cesarean for breech) received a quality rating of fair.^20^ The only moderately relevant study was of poor quality. The remaining two studies were of low relevance to CDMR and were not graded for quality.

An often quoted statistic included in a letter to the editor by Hall and Bewley, extrapolates a higher relative risk (RR) of mortality associated with elective (RR: 2·84. 95% CI 1.72–4.70) and emergency cesarean (RR: 8·84, 95% CI 5.60–13.94) compared with vaginal delivery.^113^ However, careful examination of the original source of their data finds that “elective” cesareans included no CDMR. In fact, “in many cases of elective cesarean section the woman had significant underlying medical problems, such as primary pulmonary hypertension, or other cardiac disease.”^114^

Furthermore, comparisons are not made by planned routes of delivery but rather actual routes of delivery. In an appropriate analysis, mortality associated with planned vaginal deliveries would include maternal deaths following both actual vaginal deliveries and unplanned cesarean deliveries.

Overall, the incidence of maternal mortality was very low. This finding may be an artifact of our restricting our review to studies from developed countries where maternal mortality is generally low (e.g., in the range of 1 in 10,000 cases).^115^ Other factors related to the overall low rate of maternal mortality include ready access to antibiotics, emergency cesarean, anesthetic specialists, and blood banking capabilities.

Infection. The 12 studies that included maternal infection as an outcome provided weak evidence regarding its association with planned vaginal and planned cesarean delivery.^20,^ ^28,^ ^39,^ ^45,^ ^49,^ ^51,^ ^64,^ ^67^–^70,^ ^84^ Generally, the risk of maternal infection was lower with planned cesarean than with unplanned cesarean delivery and lower for vaginal than for cesarean delivery.

The failings in this evidence stem primarily from a lack of appropriate comparison groups, a lack of consistency in outcome definitions, and the frequent use of composite outcomes that combine infectious and noninfectious outcomes or combine infectious outcomes of differing severity. Some studies reported specific maternal infections, whereas others grouped infectious outcomes into a single measure of maternal infectious morbidity or combined infectious outcomes with unrelated outcomes such as blood loss, bladder paralysis, ileus, hematoma, or an undefined “other” category. Also problematic was that studies that used composite measures of infectious morbidity often combined outcomes with significantly different severities such as urinary tract infection (UTI), endometritis, and pneumonia. These limitations preclude our ability to make conclusive assessments of the maternal infection literature.

Anesthetic complications. Two studies showed a lower rate of anesthetic complications with planned vaginal than with planned cesarean delivery;^51,^ ^69^ the third reported no significant difference between these two routes.^50^ This is at best weak evidence suggesting a lower rate of anesthetic complications with planned vaginal delivery. The finding results from only two articles: one based on administrative data and the other that did no statistical testing. Given the increase in the use of regional anesthesia (epidural and spinal) in both planned vaginal and planned cesarean deliveries, analyzing anesthetic outcomes by intent-to-treat is especially important as was done by two of the three studies.^50,^ ^51^ The weakness of this evidence is attributable to the paucity of studies, the lack of consistent definitions, and the inclusion of possible confounders (potentially higher rate of general anesthesia used for emergency cesareans and potentially higher rates of vacuum, forceps, and cesareans in labor associated with the use of epidurals.

Hemorrhage and blood transfusion. Eleven studies provided moderate strength of evidence showing a lower risk of hemorrhage and blood transfusion in planned cesareans than in vaginal delivery.^20,^ ^28,^ ^38,^ ^39,^ ^45,^ ^50,^ ^51,^ ^64,^ ^67^–^69^ These studies also yielded evidence of lower hemorrhage or blood transfusion in planned cesareans than in unplanned cesareans.

Of these 11 studies, 1 was the initial report from the Breech Trial,^20^ 6 studies were of moderate relevance,^28,^ ^38,^ ^39,^ ^45,^ ^50,^ ^51^ and 4 were of low relevance.^64,^ ^67^–^69^ Of the moderately relevant studies, 3 were of fair quality^38,^ ^39,^ ^51^ and 3 of poor quality.^28,^ ^45,^ ^50^

The majority of the evidence showed a lower risk of blood loss associated with planned cesarean than with both planned vaginal delivery and unplanned cesarean delivery; this finding was consistent across the Breech Trial and two other fair-quality studies.^20,^ ^38,^ ^51^

Several challenges arise in interpreting this body of evidence. The studies often compared actual, rather than planned, routes of delivery; frequently, they compared only various types of cesarean delivery and lacked a vaginal comparison group. Studies also varied in their definition of excess blood loss from a gross estimation of increased blood loss to an objective and clinically meaningful definition of blood transfusion. Some studies used retrospective data (e.g., at times relying on International Classification of Diseases, Ninth Edition [ICD-9] codes, which may be of questionable reliability for this outcome).

Hysterectomy. Three studies (the Breech Trial, one study of moderate relevance, and one of low relevance) yielded weak evidence on the association between emergency hysterectomy after childbirth and either planned vaginal or planned cesarean delivery. These studies generally lacked the power to examine rare outcomes: a total of three peripartum hysterectomies were performed in all included studies. Although a hysterectomy is certainly a profound event for women who experience it, the number reported in these studies is insufficient to draw firm conclusions regarding the risk associated with either delivery route.

Thromboembolism. We have only weak evidence about any association between thromboembolism and planned vaginal or planned cesarean delivery. Studies did not consistently report a significantly higher rate of thromboembolic events associated with planned cesarean. In the only moderately relevant study (fair quality) that compared cesarean and vaginal deliveries,^39^ the rate of deep vein thrombosis was higher for both planned “without labor” and unplanned “with trial of labor” cesareans, but the risk was significant only for the unplanned group. The remaining moderately relevant study (poor quality) limited comparisons to various types of cesareans and reported a higher (nonsignificant) thrombosis rate in the unplanned cesarean group.^28^

Of the four low-relevance relevant studies, three did not show either a significant difference or consistent direction for thromboembolism risk between planned cesarean and planned vaginal delivery.^67,^ ^68,^ ^70^ The fourth study reported that the rate of thromboembolic events was statistically higher in unplanned cesareans than in planned cesarean deliveries;^69^ a subanalysis showed that thromboembolism was lower in “uncomplicated” vaginal delivery than in elective cesarean delivery.

For risks of thromboembolism, the number of moderately relevant studies was small; outcomes were rare (usually under 1% for either arm); definitions were inconsistent; and results from the two trials of planned vaginal versus cesarean delivery for breech conflicted.^20,^ ^84^ The lack of consistent direction of effect limits our ability to draw any firm conclusions regarding the risk of thromboembolism associated with CDMR.

Surgical complications. Ten studies provided weak evidence on surgical complications associated with planned vaginal and planned cesarean delivery. These included the Breech Trial,^20^ 3 studies of moderate relevance (2 of fair quality^38,^ ^51^ and 1 of poor quality^28^), and 6 of low relevance.^64,^ ^67^–^70,^ ^75^ Studies generally showed a lower risk of surgical complications in planned “elective” cesarean than in unplanned “emergency” or “labored” cesarean deliveries. When investigators expanded definitions of surgical complications to include obstetrical perineal trauma and compared actual instead of planned routes of delivery, the evidence shows a significantly higher rate of obstetrical trauma among spontaneous vaginal deliveries and assisted vaginal deliveries than among elective cesarean deliveries. Of course, perineal trauma does not occur when cesarean delivery is scheduled; consequently, planned vaginal birth and emergency cesareans are the only routes expected to be associated with perineal trauma, so it would be more common in those circumstances. Clearly, surgical complications such as fourth-degree lacerations or abdominal wound infections are associated with actual vaginal and cesarean deliveries, respectively.

We had not designed this review to provide a comprehensive assessment of obstetrical trauma among vaginal deliveries. Nonetheless, obstetrical injury can be reduced by changing clinical practice. For example, reducing routine use of episiotomy (according to a recent review from this same team) is likely to reduce the risk of obstetrical injury.^116^ A recent review suggests that antenatal perineal massage may reduce perineal trauma during birth and pain afterwards.^117^

We encountered significant challenges in summarizing the risk of surgical complications associated with a planned “elective” cesarean delivery. Chief among these were the variable relevance of included studies; use of individual measures in some studies and composite measures in others; and differences in comparison groups across studies, comparison in some studies with only various types of cesarean deliveries, and the recurring problem of analysis based on actual, not planned, route of delivery. Despite the consistently low risk of surgical complications overall associated with planned “elective” or “unlabored” cesarean deliveries, the wide variability in specific outcomes studied and the widespread use of inconsistent composite outcomes limits both the utility of these data and our ability to draw definitive conclusions.

Breastfeeding. Two Breech Trial articles (poor quality) provided weak evidence that although women with planned vaginal deliveries may initiate breastfeeding sooner than women with planned cesarean deliveries, they do not report any difference in the duration of breastfeeding.^18,^ ^83^ No studies among our included articles addressed the probability of either successfully starting breastfeeding if planned or attaining appropriate infant growth and development as measures of successful nutritional support from nursing. A meta-analysis of cesarean childbirth and psychosocial outcomes found that women with cesarean deliveries (planned and unplanned combined) were more likely to bottle feed than breastfeed compared with women with vaginal deliveries.^118^

Postpartum pain. Four articles (from three studies) reported on postpartum pain using various pain measures at different time periods.^18,^ ^43,^ ^51,^ ^83^ One was the Breech Trial (two articles were graded poor^18,^ ^83^), and the other two were of moderate relevance. Together, these studies provide weak evidence of no differences. No study reported a significant difference in pain between modes of delivery.

Psychological outcomes: postpartum depression. Two studies (the Breech Trial and another study of low relevance) provided weak evidence suggesting no differences in postpartum depression by delivery route. As with pain, the Breech Trial likely overestimated the rate of complications, interventions, and possible negative psychological outcomes in the planned vaginal delivery group.

Psychological outcomes: other. Seven articles (from six studies) yielded weak evidence about a range of other psychological outcomes; they included two articles from the Breech Trial (poor quality),^18,^ ^83^ two moderately relevant studies (one of fair quality^51^ and one of poor quality^43^), and three of low relevance.^66,^ ^76,^ ^78^ The data were consistent in reporting that women who had an unplanned cesarean delivery or an instrumental vaginal delivery were more likely to experience adverse psychological outcomes than were women who either underwent a spontaneous vaginal or a planned cesarean birth. Nonetheless, the variety of outcomes and measures makes a summative assessment of this literature extremely challenging. No studies, making appropriate comparisons, addressed maternal-infant attachment and satisfaction with the birth experience.

Maternal length of stay. Four studies, the original article from the Breech Trial (fair quality)^20^ and three of moderate relevance (poor quality)^28,^ ^43,^ ^50^ provided moderate evidence that length of stay is higher for cesarean delivery, planned or otherwise, than for vaginal delivery. Numerous external factors influence length of hospital stay, however, including insurance coverage, regional practice patterns, physician and patient preference, and neonatal hospital stay. Better measures of maternal recovery would assess quality of life, but this literature did not report on such measures.

Urinary incontinence. Nine articles (from eight studies) provided weak evidence that rates of stress urinary incontinence for planned “elective” cesarean delivery were either lower than or no different from those for vaginal delivery.^18,^ ^41,^ ^44,^ ^70,^ ^73,^ ^74,^ ^79,^ ^82,^ ^83^ The two Breech Trial articles were of poor quality; the two moderately relevant studies were of fair quality.^41,^ ^44^ Five were of low relevance.^70,^ ^73,^ ^74,^ ^79,^ ^82^

We had several challenges in interpreting the body of evidence about urinary incontinence. The articles that reported on symptoms of stress urinary incontinence generally defined this condition as some involuntary leakage of urine associated with various maneuvers such as coughing, laughing, or sneezing, but the particular definitions varied considerably, and no study used a validated urinary incontinence questionnaire. One study accounted for severity of urinary incontinence but compared groups by symptoms only.^79^ The use of questionnaires, while appropriate for this outcome, may introduce both selection and recall bias when sent to women who were not prospectively recruited for enrollment. Another problem identified is that the time period for the assessment of urinary incontinence was generally short-term and varied widely from 6 weeks to 2 years postpartum. The two studies that linked surgical administrative databases and birth registries reported outcomes from 18 to 23 years after delivery.^70,^ ^74^ Because these two studies are limited to surgery or hospitalization for urinary incontinence, they most likely select for severe incontinence and may not fully capture the prevalence and association of mild and moderate urinary incontinence with mode of delivery. All the other studies reported on symptoms of urinary incontinence and captured milder forms of incontinence, but the followup periods were short.

Finally, only four studies accounted for preexisting urinary incontinence.^41,^ ^44,^ ^79,^ ^82^ In short, numerous problems limit evidence on this outcome: lack of high-quality prospective studies that compare planned routes of delivery, have adequate power, include comprehensive long-term followup, account for multiple deliveries, account for variations in practice patterns including use of epidural anesthesia and episiotomy, use validated urinary questionnaires administered at consistent time points from delivery, and define incontinence in a standardized fashion by its occurrence, severity, and impact on quality of life. We note that future research should include studies of pathophysiological pathways for pelvic floor disorders.

Recent studies have attempted to identify unique populations to study the influence of mode of delivery on future risks of urinary incontinence and have arrived at conflicting results. Buchsbaum et al. compared urinary incontinence in a group of nulliparous nuns with their parous sisters and found no statistically significant difference between these groups suggesting a familial influence not related to mode of delivery.^119^ Conversely, Goldberg et al. compared urinary incontinence among identical twin sisters and found that incontinence was associated with age, obesity, and mode of delivery with vaginal delivery conferring an increased risk relative to cesarean delivery (OR 2.28, CI 1.14–4.55).^120^ We note that a fundamental difference between these two studies is the age of the populations. The mean age of patients in the Buchsbaum study was 61 years compared with 47 years in the Goldberg study. This difference suggests that urinary incontinence is likely multifactorial and that any reduced risk associated with CDMR may be overridden by age. Future research should consider risks of urinary incontinence associated with cumulative pregnancies and deliveries, as any protective effect afforded by CDMR may also be reduced with increasing parity.

Anorectal function. Seven articles (from six studies) provided weak evidence showing a reduced risk of anal incontinence in planned cesarean deliveries compared with unplanned cesarean or instrumental vaginal deliveries. There was inconsistent evidence of difference between planned cesarean and spontaneous vaginal delivery. The two Breech Trial articles (poor quality)^18^ did not show any significant differences in fecal incontinence at either 3 months or 2 years, but several factors make it difficult to draw conclusions from this trial. It was designed to focus primarily on neonatal outcomes following planned vaginal versus planned cesarean for breech. It used different measures of anorectal function at each of the two time points, included multiparous women, allowed randomization in labor, had a high degree of crossover, was performed in 26 countries, and used nonvalidated instruments in multiple languages with more than 50 percent of participants requiring assistance in completing the questionnaire.

Of the remaining five articles, two were moderately relevant (fair quality)^42,^ ^46^ but varied in their comparison groups, timing of assessment, and questionnaires used. One assessed severity and reported lower rates (3 of 80 women) of new onset anal incontinence in the elective cesarean group;^46^ two of these cases were of higher severity, suggesting that pregnancy itself might lead to anal incontinence. The other study reported a significantly lower rate of flatal incontinence but not fecal incontinence at 6 months in the planned “elective” cesarean than in the unplanned “in labor” cesareans.^42^ The remaining studies were of low relevance to CDMR.

As with studies on urinary incontinence, the limited sample sizes and lack of a consistent direction of effect precludes definitive interpretation. Other factors also impede interpretation: studies used various instruments, often either completely unvalidated or unvalidated in the language of the study population; and studies were small and thus unable to characterize this disorder fully; studies lacked a consistent time period for assessment of anal incontinence and varied in the definitions used (some restricting their definition to incontinence of fecal matter and others including incontinence of flatus). Until studies adopt a more uniform set of operational definitions and outcome measures, information on this outcome will continue to be scanty and problematic.

Pelvic organ prolapse. We found no evidence on the association between pelvic organ prolapse and planned vaginal or planned cesarean delivery. A single study of low relevance (from an administrative data set) examined hospitalization for either “vaginal descensus” or urinary incontinence as one of several secondary outcomes associated with actual modes of delivery.^70^ Because of a possible typographical error in the results section of the article, we could not make any definitive comments about this article or outcome.

Sexual function. Two Breech Trial articles (poor quality) provided weak evidence that sexual function does not differ by planned route of delivery.^18,^ ^83^ This study used unvalidated measures that were administered in multiple languages and required the assistance of translators.

Maternal outcomes relevant to subsequent cesarean delivery. As noted in previous chapters, our systematic review focused on primary cesarean deliveries. The following discussion is limited to summaries or updates of existing systematic reviews for three outcomes that we believe are of interest to the SOS conference panel.

Subsequent fertility issues. We found no evidence on the association between subsequent fertility issues and planned vaginal or planned cesarean delivery among our included articles. A review of cesarean deliveries on future pregnancy noted that the procedure is a risk factor for lowered fertility, for uncompleted pregnancy, for complications in the next pregnancy and birth, and for health problems in the next infant. The study notes that all reviews potentially suffer from selection bias by indication and that reproductive outcomes after a cesarean delivery can be attributed to either the cesarean or to factor causing it.^121^ As with subsequent stillbirth, the issue of potential bias reduces the utility of these findings to CDMR.

Subsequent uterine rupture. A recent update^32^of a systematic review^96^ on the outcomes of vaginal birth after cesarean (VBAC) provided moderate evidence on subsequent uterine rupture. The update found no statistically significant differences between trial of labor after cesarean and elective repeat cesarean delivery with regard to rates of asymptomatic uterine rupture rates. The update noted that two studies of fair or good quality found a small but higher risk of symptomatic uterine rupture in trial of labor after cesarean than in elective repeat cesarean delivery (2.7 per 1,000).^97,^ ^122^ A large multicenter prospective observational study of 33,699 women carrying singleton pregnancies following earlier cesarean delivery provided similar evidence: the study reported an incidence of uterine rupture of 0.7 (124 per 17,898 deliveries) for a trial of labor and no cases of uterine rupture for elective repeat cesarean delivery (0 of 15,801 deliveries). Maternal death and hysterectomy did not differ between groups.^123^

Placenta previa. Given that placenta previa is the most common placental implantation anomaly, we updated a recent meta-analysis by Faiz and Ananth examining the relationship between placenta previa and a history of cesarean delivery.^31^ Our update supports the earlier meta-analytic conclusion that placenta previa is associated with advancing maternal age and increasing parity. The literature provided moderate evidence that the risk of placenta previa increases with previous cesarean delivery.

Subsequent stillbirth. The only study we found (low relevance to CDMR) did not show a difference in the rates of subsequent stillbirth among elective cesarean, emergency cesarean, and vaginal delivery.^70^ This study followed a cohort of breech deliveries and did not control for breech presentation in subsequent deliveries; the results are of limited utility to CDMR. A recent retrospective cohort study by Smith et al. suggested a twofold higher risk of stillbirth in subsequent pregnancies in women who had had a previous cesarean than in women who had delivered only vaginally (3.8 per 1,000 vs. 2.3 per 1,000, respectively).^124^ The authors did not record the indication for the first cesarean delivery, however, and the higher risk of stillbirth observed may have been associated with the medical conditions that warranted the cesarean deliveries in the first place, not the cesarean deliveries themselves. The issue of potential bias reduces the utility of these findings to CDMR.

Neonatal outcomes. Table 32 provides the direction of effect and strength of evidence for the neonatal outcomes for which we sought evidence in this review. The evidence was either weak or nonexistent for every outcome examined.

Fetal mortality. We found no studies that addressed fetal (in utero) deaths. Fetal mortality can occur at any gestational age, including at term or postterm.^125^ A purported benefit of CDMR is the prevention of fetal (in utero) death in late-term or post-term pregnancies. A comprehensive assessment of CDMR ought to compare fetal deaths at all gestational ages by planned route of delivery.

Neonatal mortality. One study of moderate relevance (fair quality)^53^ and one of low relevance^81^ provided weak evidence on neonatal mortality. The moderately relevant study compared “elective” cesarean with vaginal delivery. This study reported no neonatal mortality but was underpowered for such a rare outcome.^53^

The low relevance study used a large administrative data set that offered a sample size sufficient to examine rare outcomes, but its retrospective classification of mode of delivery limited its usefulness. For instance, the classification of the cesarean deliveries was limited to either “labored” or “unlabored.” The unlabored cesarean deliveries likely included emergency cesareans and those performed for serious maternal and neonatal indications such as placenta previa, severe preeclampsia, breech presentation, fetal distress, and major fetal anomalies. Such maternal and neonatal disorders could seriously affect neonatal mortality and seriously confound the underlying association between neonatal mortality and mode of delivery.

Unexpected (iatrogenic) prematurity. We found no study that addressed unexpected prematurity and allowed comparisons by type of cesarean with intended or actual vaginal delivery.

Respiratory morbidity. Measures of respiratory morbidity range from transient tachypnea of the newborn (TTN) to severe respiratory distress syndrome (RDS) with long-term sequelae. Overall, nine articles (for eight studies) yielded moderate evidence on the association of neonatal respiratory problems and delivery route.^47,^ ^48,^ ^51^–^53,^ ^65,^ ^77,^ ^80,^ ^81^ Four studies of moderate relevance (fair quality) suggested that the risk of variably defined “respiratory morbidity” was higher for all cesarean births than for vaginal deliveries. This finding is consistent with the long-held belief that neonatal passage through the birth canal improves the neonatal pulmonary transition from amniotic fluid to breathing air. No study assessed TTN and RDS and also stratified results by gestational age.

We did not find sufficient evidence to determine whether gestational age alone accounts for the differential risk of respiratory neonatal morbidity associated with cesarean delivery. Five articles (from four studies) that accounted for gestational age consistently reported a significant reduction in the risk of neonatal morbidity as gestational age advanced, approaching equality at 39 to 40 weeks.^48,^ ^52,^ ^53,^ ^77,^ ^80^

Clinicians believe that the experience of labor itself results in a lower risk of neonatal respiratory morbidity (TTN and RDS), but we found no conclusive evidence that labor before cesarean delivery offers a protective effect. This may be due to confounders such as inclusion of meconium aspiration syndrome in a composite measure of respiratory distress.

One of four studies that compared TTN and RDS between prelabor and labored cesarean deliveries showed a lower risk of respiratory morbidity in labored cesarean deliveries.^48^ However, the remaining three studies showed a higher risk of respiratory morbidity in labored cesarean deliveries.^47^

We cannot determine whether the higher risk of respiratory morbidity associated with labored cesarean deliveries in these three studies is due to TTN, RDS, or MAS. Similarly, we cannot determine whether the higher rate can be attributed to a higher rate of emergency cesarean for complications relating to prematurity.

The pathophysiological mechanism by which labor may influence the risk of respiratory morbidity associated with TTN and RDS is unclear and may extend beyond the physical effects of labor on the fetus (thoracic compression).

Finally, we found insufficient evidence to be able to comment on meconium aspiration syndrome.

Transition issues. The same low relevance study^81^ reported on this outcome, but the significant issues of appropriate categorization in this study make interpreting the data difficult. We consider the available evidence insufficient to judge the direction of effect.

Neonatal asphyxia or encephalopathy. Two studies provided weak evidence of a higher risk of neonatal encephalopathy associated with operative vaginal deliveries and “emergency” or “labored” cesareans than with spontaneous vaginal delivery. One case-control study of moderate relevance (fair quality) found a significantly reduced risk of neonatal encephalopathy associated with planned “elective” cesareans deliveries.^37^ The large administrative database study (low relevance) found an increased risk of convulsions and central nervous system depression associated with “prelabored” cesareans than with spontaneous vaginal deliveries.^81^

These studies have differing relative strengths. The moderately relevant study has a superior proxy for planned cesarean delivery, but as a case-control study it cannot be used to comment on absolute risks. The low relevance study is appropriate for calculating absolute risks; however, the study defined the key comparison group as “unlabored” cesarean and may, therefore, include cesareans performed because of nonreassuring fetal status, which represents a significant confounder for route of delivery and for this particular outcome.

Intracranial hemorrhage. The administrative database study (low relevance) also provided weak evidence on intracranial (subdural/cerebral, intraventricular, and subarachnoid) hemorrhage.^81^ The prelabor cesarean deliveries included those done for maternal or neonatal indications, so they likely involved cesareans for placenta previa and fetal anomalies, which may independently increase the risk of intracranial hemorrhage. Despite the higher theoretical risk for prelabor cesarean deliveries, this study did not find any significant difference between spontaneous vaginal delivery and prelabor cesarean deliveries. It did show consistently higher rates of intracranial hemorrhage for assisted vaginal deliveries and cesarean deliveries in labor. The results suggest that CDMR poses no greater risk for intracranial hemorrhage than does planned vaginal delivery.

Facial nerve injury. The administrative database study (low relevance) provided weak evidence that the risk of facial nerve injury varies by mode of delivery; the risk is higher for forceps and the combined use of forceps and vacuum delivery than for spontaneous vaginal delivery.^81^ These findings suggested that CDMR posed no risk for facial nerve injury greater than that associated with planned vaginal delivery.

Brachial plexus injury. The administrative database study (low relevance) provides weak evidence that the incidence of brachial plexus injury is lower in cesarean delivery than in vaginal delivery;^81^ these results are consistent with a priori expectations. In this study, the rate of brachial plexus injury was significantly higher in vacuum, forceps, and the combined attempt at vacuum and forceps deliveries than in spontaneous vaginal delivery. The rate of brachial plexus injury was significantly lower for cesareans overall and for those performed after labor than for spontaneous vaginal delivery; it was also lower (approaching statistical significance) for cesareans performed before labor than for spontaneous vaginal delivery. Clinicians generally accept that shoulder dystocias and resultant brachial plexus injuries are primarily associated with vaginal deliveries. To what extent brachial plexus injuries resolve spontaneously or results in long-term permanent disability has not been clearly documented.

Fetal laceration. Two studies of moderate relevance (poor quality) provided weak evidence on fetal lacerations based on data limited to cesarean deliveries. They reported a higher rate of fetal lacerations among emergency and labored cesarean than among elective cesarean delivery.^28,^ ^40^ The higher risk of fetal laceration associated with an emergency or labored cesarean may have several explanations: entering the uterus more rapidly in cases of fetal distress, having a thin lower uterine segment after labor, and having less or no amniotic fluid after rupture of membranes (which places the fetal skin in almost direct contact with the uterine wall). These results suggested that CDMR posed no additional risk for fetal lacerations beyond those associated with planned vaginal delivery.

Neonatal length of hospital stay. One study (two articles) of moderate relevance (fair quality) provided weak evidence that the neonatal length of hospital stay is higher for “elective” cesarean delivery than for vaginal delivery.^52,^ ^53^

Long-term neonatal outcomes. We did not find any evidence on long-term neonatal outcomes.

### KQ 3: Modifiers of Cesarean Delivery on Maternal Request

The evidence on effect modifiers is sparse and pertains to only a few outcomes for KQ 2. Five studies provided evidence on the modifiers of CDMR, specifically neonatal respiratory distress,^53,^ ^55^ infectious morbidity,^54^ and urinary incontinence.^82^

With regard to respiratory morbidity, results showed a consistent decrease in respiratory morbidity as gestational age rises, despite differences in inclusion criteria and definitions of elective cesarean delivery.^48,^ ^53,^ ^55^ Gestational age appears to play a lesser role as a risk factor for fetal respiratory distress in planned vaginal delivery than in planned cesarean.

With regard to infectious morbidity, the single study we found suggested no effect of physician experience, incision type, maternal age, or prophylactic antibiotics on infectious morbidity; it did suggest that the risk was higher among obese or black patients than among other women.^54^ Pelvic floor exercises decreased the risk of urinary incontinence; prepregnancy body mass index (BMI) increased it.^82^

Given the lack of evidence directly comparing effect modifiers in a population with planned CDMR with those in a population with planned vaginal delivery, inferences about effect modifiers must be drawn cautiously. Furthermore, most studies did not adjust for confounders, so results must be interpreted as crude estimates.

A multitude of factors can conceivably affect outcomes of planned CDMR and planned vaginal delivery. An extensive body of literature exists on how factors such as comorbidities, settings, and patient characteristics influence outcomes of vaginal delivery, but reviewing it was beyond the scope of this report. Furthermore, indirectly comparing results of these studies with results of studies on planned CDMR could be misleading because of the heterogeneity of populations, differences in definitions, and varying standards of care.

## Limitations of Our Review

We designed our search strategies to answer questions for the SOS conference scheduled for March 2006. Thus, our aim was to compare primary planned cesarean delivery (cesarean delivery on maternal request, or CDMR) with planned vaginal delivery. Time and resources did not permit us to review comprehensively the benefits and harms associated solely or primarily with vaginal delivery, or with repeat cesarean deliveries.

In addition, for similar time and resource reasons, we did not conduct dual, independent, blinded review of articles for inclusion or abstraction of information into evidence tables. Instead, one reviewer performed the initial review, and a second reviewer examined that input and recommended changes or corrections when needed. These two reviewers reconciled any differences by consensus discussion. To enable us to evaluate rigorously any systematic bias in our work, however, we did apply dual review for assigning relevance ratings, assessing the quality of individual articles, and grading the strength of evidence.

## Limitations of the Evidence Base

### Lack of Consistent Terminology

Studies lacked consistent and clear definitions of routes of delivery, maternal outcomes, and neonatal outcomes. They inconsistently took into account whether “planning” occurred before delivery, indications for cesarean, and laboring status in their categories of mode of delivery. Moreover, ambiguities and discrepancies in how outcomes were defined and measured were frequent. These variations across studies made comparing outcomes for planned routes of delivery extremely challenging and sometimes impossible.

### Inappropriate Comparisons: Planned versus Actual Delivery Modes

As explained in detail in Chapters 1 and 2, the appropriate comparison to address the SOS conference issues is that of intent: planned vaginal delivery or planned CDMR. The great majority of studies in this systematic review report outcomes by actual route of delivery. Failure to use intent-to-treat approaches can bias results.

The absence of data on appropriate routes of planned deliveries required us to use proxies for CDMR. These proxies usually compared actual routes of delivery, not planned routes of delivery, similarly leading to bias from failure to account for intent-to-treat.

The SOS Conference panel and the TEP recommended that, for proxies, we use studies comparing routes of delivery for breech presentation. We recognized the significant confounding effect this indication would have on neonatal outcomes, so we used it as a proxy only for maternal outcomes. As noted in Chapter 1, however, the extent to which studies of breech presentation serve as appropriate proxies for maternal outcomes of planned vaginal delivery compared with those of planned CDMR is unclear. For instance, the risk of infection may be higher in planned cesarean for breech, if the length of time between labor onset or rupture of membranes to cesarean delivery is higher than it would be in true CDMR. Conversely, the risk of infection in the planned vaginal delivery group may be higher because the number of women undergoing a labored cesarean is greater than the number expected in a typical population of women with vertex presentations.

### Inappropriate Study Designs

No clinical trial addressed the question of true CDMR. The only randomized controlled trial of route of delivery was for breech presentations, and it had several limitations that have been noted elsewhere in this review. Studies generally relied on retrospective data with attendant issues of poorly defined routes of delivery and outcomes. Few studies provided power calculations to support their estimates.

### Inadequate Controls for Confounders

Studies infrequently accounted for confounders such as morbid obesity, multiple gestations, placenta previa, and polyhydramnios (excess amniotic fluid) that influence the recommended route of delivery and also lead to poor maternal and neonatal outcomes. The extent to which these confounders influenced these outcomes is generally unknown because authors rarely controlled for such variables. A striking example of poor assessment of confounding arises in the studies of neonatal respiratory morbidity. Several of these studies included preterm infants, suggesting failure to account for underlying maternal or neonatal indications that could have influenced both route of delivery and respiratory outcomes.

### Inadequate Assessment of Modifiers of Outcomes

Most studies included in this systematic review do not adequately report on the standards of care associated with a particular route of delivery that could potentially modify outcomes. For instance, few studies address potential modifiers of outcomes associated with vaginal delivery such as too early hospital admission in labor, lack of adequate emotional support, electronic fetal monitoring, epidurals for pain management, laboring and pushing in bed, IV fluids, too many vaginal exams, strict time limits for duration of labor, valsalva pushing as soon as the cervix is completely dilated, lithotomy position for birth, and episiotomy. Similarly, studies do not address potential modifiers of outcomes associated with planned cesarean delivery such as variations in operative technique (single versus double layer uterine closure, extraabdominal uterine exteriorization to facilitate closure of incision or uterine massage, closure of vesicouterine (visceral) peritoneum, closure of parietal peritoneum), physician expertise, and access to emergency care. We are therefore unable to comment on whether the risks of any particular outcome are associated with “ideal” practice environments or whether these risks can be appreciably modified by changes in the practice environment.

### Inadequate Quality of Studies

Nonrandomized observational cohort studies were universally of fair or poor quality; the limitations of these studies were noted in Chapter 3 and above.

A single randomized controlled trial, the Breech Trial, was in principle the best study we had available to us because it used intent-to-treat analysis and reported on maternal surgical, pelvic floor, and pain outcomes. It offered high quality data on mode of delivery for neonatal outcomes, but the findings were specific to breech deliveries and could not be extrapolated to vertex pregnancies. We therefore excluded studies of breech deliveries from our review of neonatal outcomes.

For the broader purposes of this review, however, the Breech Trial had some limitations. It included multiparous patients and allowed women to be randomized even if in labor; it was not designed to address pelvic floor outcomes; and it had a high rate of cross-over. Finally, it used unvalidated instruments in multiple languages (as the study was done in 26 countries) and more than 50 percent of the participants required assistance in completing the questionnaires; moreover, the questionnaires changed throughout the study period, and different questionnaires were used at 3 months and at 2 years.

### Inappropriate Outcome Measures: Timing, Severity, and Utility

Studies reporting maternal and neonatal outcomes that were not immediately evident at delivery measured outcomes at varying lengths of time from delivery. This lack of a standard time period to assess long-term outcomes makes comparing studies problematic. Further, outcomes such as urinary incontinence, pelvic organ prolapse, and anal incontinence were usually measured a few weeks to a few months from delivery; they are, therefore, of limited clinical relevance. Studies that measured pelvic floor disorders more than 2 years from delivery were limited to administrative databases; they could not control for variables such as interval pregnancies and deliveries, length of labor, use of vacuum or forceps (or both), obesity, smoking, constipation or chronic straining, or previous reconstructive pelvic surgery.

The severity of the maternal and neonatal outcomes we examined for the SOS conference varied appreciably with respect to severity; the gravity of the outcomes clearly differs across such outcomes as UTI, sepsis, or death (for mothers) or across TTN, RDS, scalp lacerations, and intracranial hemorrhage (for infants). However, few studies rated the severity of any particular outcome.

No study provided any assessment of the utility (to either mothers or, by proxy, infants) of these different outcomes. Conspicuously absent was any measure of health-related quality of life in the face of different outcomes. The issue of severity rating and quality of life is particularly relevant to pelvic floor outcomes such as urinary incontinence, pelvic organ prolapse, or anal incontinence.

## Future Research Directions (Key Question 4)

Medicine is often practiced beyond the boundaries of robust research evidence. In such instances, providers and patients may experience little discomfort making decisions based on well-established patterns of care. However, when new treatments, technologies, or concepts appear that result in new patterns of care, substantial anxiety about the best way to chart a course may occur.

CDMR is an exemplar of a challenge to conventional practice that arises quickly, gains momentum, and generates numerous questions in its wake. CDMR is particularly challenging given the complexity of issues that need to be addressed both individually by the patient and provider and by society. Issues relevant to patients and providers include balancing short- and long-term risks and benefits for the woman and her infant, assessing such risks in both the first pregnancy and any subsequent pregnancies, and determining the validity and value (utility) of the benefits asserted. Societal concerns range broadly: the extent of individual autonomy to make informed health care decisions, including the choice of CDMR; the impact that CDMR may have on health care costs; ethical implications of elective surgery to avoid a physiologic process; modern medicalization of birth; influence of consumerism; fear of litigation; and motivations of the professional groups who advocate for answers.

The need for high-quality research evidence to inform care is of paramount importance. For instance, some practices, such as the use of routine episiotomy, have been adopted widely but remain without evidence of benefit.^116^ Some practices that had been widely adopted were only later proven ineffective: examples include hormone replacement therapy^126,^ ^127^ and a common arthroscopic knee surgery.^128^ Such examples force the biomedical and clinical communities and patients and consumers to acknowledge that “intuition, unsystematic experience, and pathophysiologic rationale are insufficient grounds for clinical decision-making.”^129^

Women and their providers make decisions about CDMR every day. An individual woman's desire for a CDMR may be supported or rejected by her prenatal care provider or by the clinician to whom she is referred for consultation if the original provider does not perform cesareans or does not support CDMR. Some observers suggest that few women would spontaneously request a cesarean; they hold that care providers introduce the idea with the intent (and effect) of making the option seem “normal” and prompting women to consider and, later, perhaps request CDMR. Regardless of the mechanism that leads to these discussions, at present they happen without evidence that is sufficient to bear the weight of the decision for or against CDMR.

An accurate assessment of maternal and neonatal risks and benefits associated with CDMR requires a comprehensive and explicit estimation of utility or value that women, their families, and others place on each outcome. Setting values separately on short- and long-term outcomes for mothers and for infants, in both the first and subsequent pregnancies, is challenging indeed, but it is necessary to understand fully the implications of a decision to choose CDMR.

This systematic review underscores the striking paucity of helpful data related to CDMR. The following section provides a framework for structuring future research on these topics, with particular reference to the numerous gaps and limitations that we identified.

### Terminology

The lack of standardized definitions of planned modes of delivery, required to establish valid groups for comparison of outcomes, extends to measures of maternal and neonatal outcomes. This evidence review points to a need for greater uniformity and sophistication in the collection of data, clear operational definition of the exposure groups, and improved operational definitions of the outcomes to be compared.

The fundamental difficulty with summarizing the body of literature identified was the lack of standardization of definitions for mode of delivery. Operational definitions varied widely and at times were not defined at all. Categorization of type of cesarean took many guises: maternal request, planned or unplanned, scheduled or unscheduled, emergency vs nonemergency vs urgent, labored or unlabored, “elective,” and specific maternal or neonatal indications for a particular mode of delivery.

For the benefit of this literature as well as the broader literature on birth outcomes, we strongly recommend that significant resources be designated to arriving at precise operational definitions for all applicable categories of delivery modes, including clear specification of maternal and neonatal indications. Without early consensus on these definitions, we are unlikely to arrive at reliable estimates of the trend and incidence of CDMR (or other reasons for cesarean delivery more generally) or of the benefits and harms associated with any particular mode of delivery in comparison with another.

In addition, we strongly recommend establishing a minimum data set for maternal and neonatal outcomes to help clarify the terminology but also to provide a mechanism for doing long-term prospective investigations. This will require thoughtful collaboration among appropriate stakeholders, including family physicians, midwives, obstetricians, neonatologists, pediatricians, urogynecologists, and experts in public health.

### Appropriate Study Design

Although clinical trials are the usual touchstone and highest standard for aiding clinical decisionmaking, the feasibility of conducting a trial on CDMR is questionable. Researchers will need groups of women who opt to have cesarean births based on their own desire, and not as a result of a previous cesarean, or groups of women who are willing to be assigned randomly to either scheduled cesarean or conventional expectant management and labor, which could include cesarean based on medical need.

Currently, prospective observational studies provide the best initial approach to defining and describing outcomes of planned routes of delivery adequately. However, we recognize that prospective studies may be inadequately powered to examine rare outcomes such as maternal or neonatal death, hysterectomy, or shoulder dystocia. Universal adoption of consistent terminology and recordkeeping on planned route of delivery will increase the usefulness of retrospective data in addressing rare outcomes, especially data in large administrative databases.

### Appropriate Statistical Methods and Reporting

Investigators must address a variety of statistical issues. Paramount are ensuring adequate sample size and doing power calculations. Most studies (other than those relying on surveys or administrative data) were relatively small. Some may have been underpowered for all but the most basic comparisons, and most were underpowered for subgroup analyses. Investigators should consider a priori what comparisons they want to make (and report) on the relevant power calculations. This is especially critical if researchers wish to track rare outcomes.

We recognize that some research teams may well have attended to these concerns. If so, they did not report them. Thus, we encourage those conducting trials or other studies to report all power calculations and otherwise make available data that will enable groups doing systematic reviews in the future to understand clearly and possibly use those data in quantitative analyses. In addition, we caution that researchers should take care to deal with statistical problems of multiple comparisons, possibly with appropriate corrections for statistical significance. Finally, we suggest that all research reports directly report or provide information sufficient to understand the statistical significance (or lack of it) for all reported comparisons.

### Appropriate Comparisons

Studies designed to compare outcomes of CDMR need to compare outcome by planned routes of delivery. Such intent-to-treat analysis should not, and need not, be limited to randomized controlled trials. At the current time, given the lack of any mechanism to record intent in a standardized fashion, prospective studies are the only reliable source for obtaining appropriate comparisons based on planned routes of delivery.

We strongly recommend that clinicians routinely record the planned route of delivery at term in prenatal records. Such data would allow for appropriate comparisons based on intent-to-treat even with retrospective studies. We acknowledge, however, that liability issues and fear of discord with peers, especially for conducting CDMR, might well dissuade clinicians from making such notes.

Future studies should limit the use of proxies for CDMR. Caution should be exercised in interpreting results of studies that use such proxies, because they often introduce bias from uncontrolled confounding effects. All analysts should consider carefully the potential magnitude and direction of effect from such bias.

### Important Outcomes

We draw attention to two specific outcomes, one maternal and one neonatal, that we believe require special thinking when investigators are planning future research. For mothers, reduced urinary incontinence is often cited as a major benefit of CDMR, and significant resources ought to be allocated to provide evidence to support or refute this claim. An outcome such as urinary incontinence requires a long-term, comprehensive study that assesses a wide range of variables: mode of delivery, number of births, presence and severity of urinary incontinence, and other factors that have been suggested as confounders such as constipation, smoking, and chronic cough.

For infants, the primary morbidity associated with prematurity is lung immaturity. The evidence is strong for an association between gestational age and lung maturity. For those reasons, prospectively and accurately documenting estimated gestational age and respiratory outcomes among maternal choice cesareans is critical. If CDMR rates continue to increase, clinicians and patients may tend to want to do cesareans at an earlier gestational age for maternal convenience arising from discomfort from a gravid uterus. The benefits and harms of such practices, particularly for the neonate, must be well understood by all parties, and providing that information will require additional research.

### Severity

The issue of severity rating is particularly important for pelvic floor outcomes such as urinary incontinence, pelvic organ prolapse, or anal incontinence. An undifferentiated measure of urinary incontinence that does not account for severity would mask the considerable differences in quality of life between a small amount of leakage that occurs rarely and severe and daily urinary leakage.

Similarly, neonatal outcomes such as respiratory morbidity need to be categorized and analyzed by degree of severity. For instance, TTN and RDS represent extremes of severity; investigators should not group them into a single measure of respiratory morbidity because doing so may obscure meaningful differences among groups.

### Appropriate Measures

Future studies will require a comprehensive assessment of outcomes using validated questionnaires with a standardized timing of outcome measures, with measures of severity and utility.

Comprehensive outcomes. Ideally, a systematic review of the outcomes of planned route of delivery should provide a comprehensive assessment of outcomes, accounting for the severity of symptoms and the utility of various outcomes to patients. For instance, accurate measurement of neonatal respiratory morbidity should include the risks of all forms of harm associated with planned route of delivery, including potentially higher risks of meconium aspiration in planned vaginal deliveries and potentially higher risks of TTN and RDS in planned cesarean deliveries.

Validated questionnaires. Researchers should be encouraged to use reliable and valid questionnaires for assessing outcomes such as health-related quality of life, maternal-infant attachment, birth satisfaction, pelvic floor disorders (urinary incontinence, pelvic organ prolapse, and anal incontinence), and sexual function. These instruments must appropriately capture both short- and long-term consequences of decisions related to mode of delivery. When validated instruments do not exist or are too long to administer in these circumstances, investigatators should either develop (and validate) or adapt existing ones into shorter forms.

Standardized times for outcome measurement. Ideally, outcomes should be measured over time periods that are appropriate and clinically relevant. In addition to reaching consensus on terminology, researchers in the field should develop consensus on the minimum clinically relevant time period from delivery to measurement for outcomes, particularly for outcomes of importance beyond the postpartum period.

### Confounders

Future studies need to describe and control for potential confounders of route of delivery and outcomes. The nature of these confounders may vary depending upon the specific outcome of interest.

At a minimum, studies of maternal outcomes should account for age, BMI, parity, previous cesarean deliveries, multiple gestation, maternal medical conditions such as diabetes mellitus, abnormal placental implantation (e.g., previa and accreta), and epidural use. Studies of neonatal outcomes should additionally account for gestational age, fetal presentation, and fetal anomalies or medical condition. Finally, future studies should also control for health system variables such as access to antibiotics, anesthesia, blood banking, and providers with adequate surgical training to perform an emergency cesarean delivery, which together are important components of a high standard of care.

### Utility of Outcomes

Factoring in both severity and utility when assessing the overall benefit and harm of CDMR is critically important. A woman considering a planned route of cesarean delivery needs to assess comprehensively both short- and long-term risks, to both herself and her infant, and in both the current pregnancy and future pregnancies.

Currently, clinicians and others have little or no way to judge the “priority” of a range of possible outcomes. For instance, urinary incontinence needs to be described in a manner that relates both its occurrence and severity and that provides a utility weighting relative to other potential outcomes such as wound infection. Similarly, in assessing overall harms and benefits to the neonate, the potentially higher risk of neonatal respiratory morbidity (TTN and RDS) associated with a planned CDMR needs to be weighed against the potential reduction in the rate of other outcomes such as stillbirths after 39 weeks, intrapartum deaths, and shoulder dystocias (an emergency occurring when the infant's shoulder gets “stuck”) associated with a planned vaginal delivery.

### New Areas for Research

Costs. A thorough evaluation of the costs associated with CDMR is warranted given the finite health care resources available in this country. Such a cost analysis needs to be done from various perspectives: the patient and her family, the health system (e.g., hospital, physician group), the health plan or insurance carrier (both public, as in Medicaid, and private), and the health care system more generally. To be most informative, such a cost analysis would factor in the costs associated with subsequent deliveries. It should account for all appropriate intrapartum and postpartum expenses attributable to each pathway of delivery, for both mother and infant.

We draw attention, in this regard, to the flowchart figure in Chapter 1, which documents the considerable complexity of the pathways as they diverge from initial planned route to the actual route of delivery, particularly in that the planned and actual routes diverge at different points. Whether the costs associated with the higher numbers of planned cesareans in the CDMR arm (primarily surgical costs) will be balanced by the costs associated with planned vaginal delivery (labor and delivery nursing time, supplies, epidural management, medications, and the surgical costs associated with labored cesareans) remains to be determined. Psychosocial burdens and the influence of satisfaction with the birth experience, infant feeding, and neonatal and infant development, including any decrements in maternal and infant attachment, remain uninformed by adequate comparisons; more to the point, their costs cannot be reduced to simple economic terms.

Apart from gaining data simply on costs per se, the question of cost-effectiveness may arise. Which delivery path is more cost effective is impossible to say for two reasons. First, as we have documented, little is known about the comparative effectiveness of different modes of delivery. Second, no studies compare the costs of CDMR with those of planned vaginal delivery. Thus, the task of examining any issues related to cost-effectiveness lies well into the future.

Medical and legal concerns. If the rate of CDMR were to continue to increase, how and to what degree this pattern would affect the medicolegal environment within which obstetrics is currently practiced in developed countries (particularly the United States) remains an open question. Future research in this area would help us understand to what extent a decision to perform a cesarean after labor in a woman who planned a vaginal delivery was influenced by the provider's fear of litigation. Future research could also investigate whether medicolegal exposure or malpractice insurance premiums rise or fall depending on patterns of CDMR vs. planned vaginal delivery.

## Conclusions

The incidence of CDMR appears to be increasing. However, accurately assessing its true incidence or trends over time is difficult because currently CDMR is neither a well-recognized clinical entity nor an accurately reported indication for diagnostic coding or reimbursement. More information is available on this question from nations other than the United States, and they differ from this country in health systems, cultural attitudes, patient demographics, and other factors. Drawing inferences from non-US sources, therefore, must be done with caution.

Virtually no studies exist on CDMR per se, so the knowledge base rests chiefly on indirect evidence from proxies such as cesareans performed for breech presentation. These proxies each possess unique and significant limitations. Furthermore, the vast majority of studies to date compared outcomes by actual routes of delivery, not planned routes of delivery. Therefore, significant uncertainty remains regarding the “ideal” route of delivery. Primary CDMR and planned vaginal delivery likely do differ with respect to individual outcomes for either mothers or infants. However, our comprehensive assessment, across many different outcomes, suggests that no major differences exist between primary CDMR and planned vaginal delivery, but the evidence is too weak to conclude definitively that differences are completely absent. If a woman chooses to have a cesarean delivery in her first delivery, she is more likely to have subsequent deliveries by cesarean. With increasing numbers of cesarean delivery, risks occur with increasing frequency.

Given the limited data available, we cannot draw definitive conclusions about factors that might influence outcomes of planned CDMR vs. planned vaginal delivery. Neither is the knowledge base adequate to comment definitively on many factors that influence the outcomes of actual cesarean and vaginal deliveries.

Our review focused on primary CDMR. We note that a comprehensive assessment of the risks and benefits of CDMR extends beyond the first cesarean. Future research needs to account for complications and risks associated with repeat cesarean deliveries such as adhesions, placenta previa and accreta, and subsequent stillbirths.

Significant resources will need to be allocated to study CDMR if the nation is to be well informed about the benefits and harms to mothers and infants in both the first and subsequent pregnancies. To realize the maximum gain from such work, research intended to answer questions about maternal and neonatal outcomes of CDMR must study them by intent-to-treat methods. This means comparing outcomes of planned CDMR with those of planned vaginal delivery, not comparing outcomes by actual routes of delivery.

Future research efforts need to focus on a substantial set of problems: developing consensus about terminology for both delivery routes and outcomes; creating a minimum data set of information about CDMR; improving study design and statistical analyses; attending to major outcomes and their special measurement issues; assessing both short- and long-term outcomes with better measurement strategies; dealing better with confounders; and considering the value or utility (in quality-of-life terms) of different outcomes. Examining the costs and cost-effectiveness of different pathways of delivery and considering the impact of CDMR on the medicolegal system also warrant attention.

Finally, if we are to gain meaningful data on short- and long-term maternal and neonatal outcomes associated with CDMR (whether or not compared with planned vaginal delivery), we should define success as a healthy mother and infant in the broadest sense of well-being possible. Studies ought to be well-designed, prospective, with adequate sample sizes and clearly described power analyses for both common and rare outcomes. Accumulating such high-quality evidence is possible with cooperation from all stakeholders; acquiring it is imperative if women and care providers are to be able to make informed decisions about CDMR.