# Results

This chapter presents the results of our evidence review for the first three key questions (KQs): (KQ 1) trend and incidence data; (KQ 2) outcomes of cesarean delivery on maternal request (CDMR), proxies for CDMR, and various comparison routes of delivery; and (KQ 3) modifiers of outcomes. These KQs are the principal focus of a March 2006 State of the Science (SOS) conference being convened by the Office of Medical Applications of Research (OMAR) at the National Institutes of Health (NIH). KQ 4, on future research, is covered in Chapter 4 of this report. Appendix C * provides the detailed evidence tables for KQ 2.

* Appendixes and Evidence Tables for this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/cesarean/cesarreq.pdf

As explained in Chapters 1 and 2, we rated studies for their relevance to the comparisons of interest for the SOS conference, using four categories. Three categories related mainly to observational studies: high (H), moderate (M), and low (L) relevance; none of these compared outcomes prospectively by planned route of delivery for both cesarean and vaginal delivery. The fourth category comprised two studies comparing outcomes from prospectively assigned planned routes of delivery: a nonrandomized study of a “trial of labor” (assigned by department) and the other a randomized trial, known as the International Term Breech Trial (Breech Trial); they are both denoted by T; both studies used intent-to-treat analyses.

With one exception for KQ 1, no included studies were rated highly relevant. Of the remainder, most are of only low relevance because they were designed to address hypotheses or clinical issues other than the ones of interest for this systematic review.

We have already noted the extreme profusion of terms in this field and the fact that clinicians, investigators, and others do not apply them consistently across this evidence base. Moreover, the terms and phrases do not map consistently (or necessarily accurately) to the conceptual framework and definitions that we articulated for this systematic review. For that reason, in reporting on studies in this chapter we have put quotation marks around certain terms or phrases to indicate that they represent the usage of the authors of those studies, not necessarily our usage.

## Key Question 1: Trends and Incidence of Cesarean Delivery

The SOS planning group specified that the first issue we should address involved the following points concerning the epidemiology of cesarean delivery in general and CDMR (or possible proxies) in particular. They posed the questions as follows:

First, what is the trend and incidence of cesarean delivery over time in the United States and in other developed countries?

Secondarily:

a What is the contribution of primary prelabor cesarean deliveries?
b Of the primary prelabor cesarean deliveries, what is the contribution of cesarean delivery on maternal request (i.e., CDMR), for medical indications, and for malpresentation?

We answer these questions on the basis of both published articles and web-based sources (a form of gray literature). However, we report incidence data before trend data, because the former are a part of the latter. Because of the focus on the United States and then other developed countries, our main approach in this section is by country.

### Literature Relevant to the Epidemiologic Questions

Overall, we identified 13 published studies reporting the incidence and trends of modes of cesarean section. Of the 13 articles, we gave 1 study a relevance rating of high,^33^ 3 studies a rating of moderate,^34^–^36^ and 9 studies a rating of low.^3,^ ^56^–^63^ We also found web-based sources for four regions: United Kingdom^86^ and three states in Australia (Victoria,^87^–^89^ South Australia,^90^ and New South Wales^91^). All of the Web-based sources were moderately relevant to CDMR. Two published studies were conducted in the United States,^3,^ ^56^ 3 in the United Kingdom,^33,^ ^60,^ ^61^ 3 in Australia,^34,^ ^57,^ ^58^ 2 in the Republic of Ireland,^35,^ ^59^ and 1 each in Norway,^36^ Finland,^62^ and Denmark.^63^ We also found web-based sources reporting rates of “elective” cesarean delivery for the United Kingdom^86^ and three states in Australia (Victoria,^87^–^89,^ ^92^ South Australia,^90^ and New South Wales^91^).

Four articles supplied trend data from the United States^3^ and Australia.^34,^ ^57,^ ^58^ Three of the four web-based sources provided trend data.^86,^ ^87,^ ^91^ With the exception of two published studies that obtained data from surveys usually sent to medical directors,^59,^ ^61^ all other studies gathered data from administrative databases or materials (e.g., birth certificates). Except for one study,^33^ all were conducted retrospectively.

### Overall Estimates of Incidence and Trends

Rates of incidence and trends of cesarean delivery vary by country. In general, countries report rising trends of cesarean delivery, with recent incidence rates at 29 percent for the United States^2^ and 23 percent for the United Kingdom.^86^ In the following section, we present data on incidence and trends of cesarean delivery by country. We also present rates of primary prelabor cesarean, CDMR, cesarean for medical indications, and for malpresentation, when available; studies rarely provided sufficient information to answer this key question. Four studies report on primary prelabor cesarean,^3,^ ^34,^ ^35,^ ^56^ and one study reports on CDMR.^33^ Other studies use variable definitions of “elective” or “planned” cesarean delivery, denoted in quotes in the text. We present summary tables for each country, with each study listed in alphabetical order by last name of first author.

### Country-Specific Incidence and Trend Data

United States. Incidence. In 2001, the rate of cesarean delivery was more than 25 percent.^3^ Studies from two sources suggest similar primary prelabor “elective” cesarean rates: 4.25 percent^56^ and approximately 5 percent^3^ of all deliveries in 1995. The definition of elective primary cesarean delivery in both studies includes malpresentation, antepartum bleeding, herpes, severe hypertension, uterine scar, multiple gestation, macrosomia, unengaged head, soft tissue condition, other hypertension, preterm, fetal anomaly, and unspecified, resulting in a definition of “elective” cesarean delivery that has low relevance to CDMR (Table 6).

Table 6 United States, incidence and trend data

Source | Study Objective | Definitions and Inclusion-Exclusion Criteria | Incidence and Trend Data
Groups | Source
Relevance Rating | Time period
Gregory et al., 2001^56^ | Objective: to describe variation in elective primary cesarean rates by nonclinical factors | Primary prelabor elective: first cesarean delivery, patient did not labor and underwent cesarean delivery with respect to the following 13 categories: malpresentation, antepartum bleeding, herpes, severe hypertension, uterine scar, multiple gestation, macrosomia, unengaged head, soft tissue condition, other hypertension, preterm, fetal anomaly, and unspecified. | Incidence:
Groups | Retrospective | Emergency: decision made after labor | G1: 463,196
G1: total cesareans | Discharge data and American Hospital Association data | Excluded: Hospitals with < 200 deliveries, women with history of cesarean | G1a: 19,664 (4.25% of total deliveries)
G1a: primary prelabor elective | 1/1/1995-12/31/1995 | | Trend:
Low | | | NR
Meikle et al., 2005^3^ | Objective: to describe national trends for elective primary cesarean delivery from 1994 to 2001, with attention to changes in indications | Primary prelabor elective: first cesarean delivery: a procedure that occurred before labor and without a previous history of cesarean delivery. Used 13 indications for elective cesarean previously reported in Gregory et al. above ^56^ | Incidence:
Groups | Retrospective | Excluded: women who labored and previous cesarean deliveries | See below for 2001
G1: primary prelabor elective | NIS database | | Trend:
Low | 1994-2001 | | G1: Primary prelabor elective cesarean deliveries (% of all deliveries)
| | | 1994: 16,036 (19.7%)
| | | 2001: 281,698 (28.3%)

Trends. Meikle et al. reported a rise in the primary elective cesarean deliveries as a proportion of all deliveries from approximately 5 percent in 1994 to approximately 7 percent in 2001.^3^ The authors also reported a rise in elective primary cesarean deliveries as a proportion of all cesarean deliveries from 19.7 percent in 1994 to 28.3 percent in 2001.

United Kingdom. Incidence. One study from Scotland offers the only evidence of high relevance to CDMR that we identified.^33^ From a prospective administrative dataset for 1994, the authors reported total cesarean deliveries (including multiple and unknown gestation) of 16 percent. The authors also reported a CDMR rate of 7.7 percent and an “elective” cesarean delivery rate for breech presentation of 19.1 percent of all singleton cesarean deliveries (Table 7). Two other studies from the United Kingdom did not define “elective” section, resulting in low relevance to CDMR. These studies used different sources. One study, using data from the Royal College of Obstetrics and Gynecology annual surveys, reported a total cesarean rate of 18.5 percent and an “elective” cesarean rate of 9.5 percent of all births from January 1997 to March 1998.^61^ The other study, using data from the National Health Service (NHS) episode statistics database, reported a total cesarean rate of 20.1 percent and an “elective” cesarean rate of 8.9 percent of all births for 2001-2002.^60^

Table 7 United Kingdom, incidence and trend data

Source | Study Objective | Definitions and Inclusion-Exclusion Criteria | Incidence and Trend Data
Groups | Source
State | Time period
Relevance Rating
Barley et al., 2004^60^ | Objective: To examine cesarean rates and socioeconomic status | Elective: not defined | Incidence:
Groups | Retrospective | | Total NHS births: 336, 324
G1: total cesarean deliveries | National Health Service (NHS) episode statistics database | | G1: N not reported (20.1%)
G1a: elective cesarean | 1/1/2001-12/31/2002 | | G1a: N not reported (8.9%)
Low | | | Trend:
| | | NR
Government Statistical Service^86^ | Objective: NA | Elective: planned procedure before, or at the onset of, labor (carried out immediately following the onset of labor, when the decision was made before labor) | Incidence:
Groups | Surveillance data from the Hospital Episode Statistics system, accessed via the web | Emergency: | See below for 2003-4
G1: total cesarean deliveries | | Not defined | Trend:
G1a: emergency cesareans | | | | Total | % of all deliveries
G1b: elective cesareans | | | Year | Deliveries | G1 | G1a | G1b
England | | | 1990-1 | 652,100 | 12.4 | 7.1 | 5.3
Moderate | | | 1991-2 | 643,800 | 12.9 | 7.4 | 5.5
| | | 1992-3 | 624,600 | 13.8 | 8.1 | 5.6
| | | 1993-4 | 620,200 | 15.0 | 8.9 | 6.1
| | | 1994-5 | 604,300 | 15.5 | 9.0 | 6.5
| | | 1995-6 | 592,600 | 16.3 | 9.5 | 6.9
| | | 1996-7 | 594,500 | 17.0 | 9.7 | 7.3
| | | 1997-8 | 585,000 | 18.2 | 10.4 | 7.9
| | | 1998-9 | 577,500 | 19.1 | 11.1 | 8
| | | 1999-0 | 565,300 | 20.6 | 12.0 | 8.6
| | | 2000-1 | 549,600 | 21.5 | 12.7 | 8.8
| | | 2001-2 | 541,700 | 22.0 | 12.7 | 9.3
| | | 2002-3 | 548,000 | 22.0 | 12.7 | 9.3
| | | 2003-4 | 575,900 | 22.7 | 13.1 | 9.6
Khor et al., 2000^61^ | Objective: To assess the national obstetric anaesthetic practices in relation to cesarean sections. | Elective: not defined | Incidence:
Groups | Retrospective | Emergency: not defined | Total deliveries: 608,853
G1: total cesarean deliveries | Royal College of Obstetrics and Gynecology annual surveys | | G1: 111,919
G1a: elective cesareans | 1/1/1997-3/31/1998 | | G1a: 39,308 (40.5% of G1)
G1b: emergency cesareans | | | G1b: 57,797 (59.5% of G1)
Low | | | Note: G1a+G1b do not sum to G1 due to incomplete returns
| | | Trend:
| | | NR
Wilkinson et al., 1998^33^ | Objective: to determine the indications for singleton cesarean sections in Scotland in 1994 | Elective: decision made before labor and primarily for breech presentation | Incidence:
Groups | Prospective Administrative database | Emergency before labor: performed for suspected growth retardation and/or fetal distress | All cesarean deliveries
G1: total deliveries | 1/1/1994-12/31/1994 | Emergency during labor: performed for failure to progress and/or fetal distress | 8,098
G1a: para 0 | | Included: singleton pregnancy | Elective cesareans
G1b: para 1, no prior cesarean delivery | | | G1: 3,150
G1c: para 1, with prior cesarean delivery | | | G1a: 884
Scotland | | | G1b: 571
High | | | G1c: 1,695
| | | Maternal request (subset of elective):
| | | 623 (7.7%) of all 8,098 singleton cesarean deliveries
| | | 623 (19.1%) of all 3,150 elective singleton cesarean deliveries
| | | Emergency pre-labor:
| | | G1: 1,127
| | | G1a: 592
| | | G1b: 293
| | | G1c: 242
| | | Emergency in labor:
| | | G1: 3,821
| | | G1a: 2,616
| | | G1b: 617
| | | G1c: 588
| | | Overall total (data available, singleton):
| | | G1: 8,098
| | | G1a: 4,092
| | | G1b: 1,481
| | | G1c: 2,525
| | | Trend:
| | | NR

Para, parity.

Trend. Web-based National Health Service data provide evidence that is moderately relevant to CDMR. They report trends for “emergency” and “elective” (defined as planned procedure before, or at the onset of labor) cesarean deliveries as a proportion of all births from 1990 to 2003-4.^86^ During this period, the rate of all cesareans rose from 12 percent to 23 percent. Both elective and emergency cesareans contributed to this rise. Relative to all births, the rate of elective cesarean deliveries rose from 5.3 percent in 1990 to 9.6 percent in 2003, and the rate of emergency cesarean deliveries rose from 7.1 percent in 1990 to 13.1 percent in 2003.

Ireland. Incidence. Two studies using different sources reported data on Ireland for elective cesarean deliveries. One study, rated moderately relevant, provided incidence data from the National Maternity Hospital database annual report on the rate of all cesarean deliveries and “nonemergency prelabor” cesarean deliveries in 2000 as 15.1 percent. Over a 12-year period from 1989-2000, the authors reported a nonemergency prelabor cesarean delivery rate of 3 percent of all deliveries and 30 percent of all cesarean deliveries (Table 8).^35^ Of these nonemergency prelabor cesarean deliveries, 24 percent were among primaparous women, 39 percent were primary cesarean deliveries among primiparous women, and 37 percent were among repeat cesarean deliveries. We calculated the total primary prelabor nonemergency cesarean rate to be 18.9 percent of cesarean deliveries during the 12-year period from 1989-2000. Farah et al. reported elective and emergency cesarean rates of 7.5 percent and 10.3 percent of all births, respectively, based on a retrospective survey of maternity unit directors.^59^ The authors did not define “elective”; as a result, their study has low relevance to CDMR.

Table 8 Ireland, incidence and trend data

Source | Study Objective | Definitions and Inclusion-Exclusion Criteria | Incidence and Trend Data
Groups | Source
Relevance Rating | Time period
Farah et al., 2003^59^ | Objective: To ascertain the national cesarean delivery rate for the year 1998 | Labored status and indication not reported | Incidence
Groups: | Retrospective | | Total deliveries: 51,133
G1: total cesarean deliveries | Survey (maternity unit directors) | | N (% of total deliveries)
G1a: elective | 1/1/1998-12/31/1998 | | G1: 9,077 (17.8%)
G1b: emergency | | | G1a: N not reported (7.5%)
Low | | | G1b: N not reported (10.3%)
| | | Trend:
| | | NR
Foley et al., 2005^35^ | Objective: to study the relationship between an increasing cesarean delivery rate and term neonatal seizures and peripartum deaths | Nonemergency prelabor cesarean delivery | Incidence of cesarean deliveries in 2000: 15.1% (N not reported)
Groups: | Retrospective | | Incidence over 12 years (1989-2000):
G1: total deliveries | National Maternity Hospital database annual report | | G1: 77,350
G1a: nulliparous deliveries | 1/1/1989-12/31/2000 | | G1a: 31,660
G1b: multiparous deliveries | | | G1b: 45,690
Moderate | | | All nonemergency prelabor cesarean deliveries: 2547 (3% of all deliveries, 30% of all cesareans)
| | | Primary prelabor cesarean deliveries
| | | G1a: 611 (24% of all nonemergency prelabor cesarean deliveries)
| | | Primary prelabor cesarean deiveries
| | | G1b: 1,002 (39% of all nonemergency prelabor cesarean deliveries)
| | | Repeat nonemergency prelabor cesarean delivery
| | | G1b: 934 (37% of all nonemergency prelabor cesarean deliveries)

Australia. Incidence. The majority of studies, from both published and web-based sources, defined “elective” cesarean deliveries as a procedure planned before the onset of labor (Table 9).^34,^ ^87^–^92^ Two other articles either did not define “elective” cesarean or defined it as cesarean before and during labor, and hence did not exclude cesareans for fetal distress or other emergencies.^57,^ ^58^

Table 9 Australia, incidence and trend data

Source | Study Objective | Definitions and Inclusion-Exclusion Criteria | Incidence and Trend Data
Groups | Source
State | Time period
Relevance Rating
Chan et al., 2005^90^ | Objective: NA | Elective: planned procedure before the spontaneous onset of labor | Incidence
Groups | Data from the South Australian perinatal data collection of births, accessed via the web | Emergency: undertaken for a complication: (a) before the onset of labor or (b) during labor, whether that labor is of spontaneous onset or following induction of labor | Total deliveries in 2003: 17,517
G1: elective cesareans | | | N (% of total deliveries):
G2: emergency cesareans | | | G1: 2,334 (13.3%)
South Australia | | | G2: 2,929 (16.7%)
Moderate
Centre for Epidemiology Research, 2002^91^ | Objective: NA | Elective: planned or unplanned cesarean delivery performed before the onset of labor | Incidence:
Groups | Data from the New South Wales Mothers and Babies 2001 report, accessed via the web | Emergency: performed after the onset of labor whether or not the onset of labor was spontaneous | See below for 2001
G1: emergency cesareans | | | Trend:
G2: elective cesareans | | | | Total | % of all deliveries
New South Wales | | | Year | Deliveries | G1 | G2
Moderate | | | 1996 | 85,302 | 8.2 | 9.4
| | | 1997 | 86,920 | 8.3 | 9.9
| | | 1998 | 85,072 | 8.7 | 10.3
| | | 1999 | 85,967 | 9.0 | 10.6
| | | 2000 | 86,460 | 9.9 | 11.5
| | | 2001 | 84,379 | 10.5 | 13.0
Read et al., 1990^34^ | Objective: to describe trends and patterns in the incidence of cesarean deliveries in Western Australia | Elective: a planned procedure done before the onset of labor and before spontaneous rupture of the membranes and without any procedure to produce labor | Incidence
Groups | Retrospective Administrative database | Emergency: undertaken at short notice for a complication before the onset of labor or during labor whether of spontaneous origin or induced | See below for 1987
G1: total cesarean deliveries | 1980-1987 | Excluded: infants < 500g | Trend:
G1a: emergency cesarean deliveries | | | | Prelabor primary elective* | Total deliveries (parity known, singleton)* | Percent prelabor primary*
G1b: elective cesarean deliveries | | | 1980 | 766 | 18,501 | 4.1%
Australia | | | 1981 | 834 | 21,719 | 3.8%
Moderate | | | 1982 | 836 | 21,876 | 3.8%
| | | 1983 | 853 | 22,551 | 3.8%
| | | 1984 | 828 | 22,418 | 3.7%
| | | 1985 | 999 | 22,749 | 4.4%
| | | 1986 | 1,058 | 23,290 | 4.5%
| | | 1987 | 1,139 | 23,538 | 4.8%
| | | *: calculated by authors of this report
| | | | Total | % of all deliveries
| | | Year | Deliveries (all parity, multiple gestations) | G1 | G1a | G1b
| | | 1980 | 20,520 | 11.23 | 5.89 | 5.35
| | | 1981 | 21,954 | 11.79 | 6.09 | 5.70
| | | 1982 | 22,110 | 12.54 | 6.18 | 6.35
| | | 1983 | 22,785 | 13.28 | 6.75 | 6.53
| | | 1984 | 22,663 | 13.86 | 6.98 | 6.88
| | | 1985 | 23,015 | 15.17 | 7.33 | 7.84
| | | 1986 | 23,561 | 16.64 | 7.79 | 7.86
| | | 1987 | 23,836 | 16.90 | 8.25 | 8.65
Riley and King, 2003;^87^ | Objective: NA | Elective: planned procedure that takes place before or after the spontaneous onset of labor | Incidence:
Riley and Halliday, 2001;^92^ | Data from the Victorian Perinatal Data Collection Unit, accessed via the web | Emergency: undertaken for a complication before or after the onset of labor | See below for 2000
Riley and Halliday, 1999;^88^ and | | | Trend:
Riley and Halliday, 1998^89^ | | | | Total | % of all deliveries
Groups | | | Year | Deliveries | G1 | G1a | G1b
G1: cesarean deliveries | | | 1992 | 63,795 | 17.7 | 8.0 | 9.7
G1a: emergency cesareans | | | 1993 | 63,795 | 18.1 | 7.9 | 10.2
G1b: elective cesareans | | | 1994 | 63,983 | 18.7 | 8.3 | 10.4
Victoria | | | 1995 | 62,372 | 19.1 | 8.1 | 11.0
Moderate | | | 1996 | 62,028 | 19.7 | 8.4 | 11.3
| | | 1997 | 61,311 | 20.2 | 8.5 | 11.7
| | | 1998 | 61,072 | 21.0 | 8.9 | 12.1
| | | 1999 | 61,587 | 22.8 | 11.3 | 11.5
| | | 2000 | 61,569 | 23.4 | 11.5 | 11.9
| | | 2001 | 61,064 | 25.3 | 12.3 | 13.0
| | | 2002 | 61,959 | 27.4 | 13.3 | 14.1
Roberts, et al., 1999^57^ | Objective: to examine trends in the distribution of births at and beyond term in New South Wales and in particular, to determine whether any changes are associated with changes in the obstetric practices of induction and elective cesarean deliveries | Elective: no labor | Incidence:
Groups | Retrospective New South Wales Midwives database | | See below for 1996
G1: elective cesarean deliveries | 1/1/1990-12/31/1996 | | Trend:
New South Wales | | | Year | N (G1) | %
Low | | | 1990 | 5,006 | 6.5
| | | 1996 | 5,031 | 6.6
Roberts et al., 2002^58^ | Objective: to examine recent trends in obstetric intervention rates among women at low-risk of poor pregnancy outcome | Cesarean before labor | Incidence
Groups | Retrospective New South Wales Midwives database | Cesarean after labor | Primiparous:
G1: total cesarean deliveries | 1/1/1990-12/31/1997 | Included: women with low risk pregnancy during antenatal care (20 to 34 years of age with no medical or obstetric complications and a singleton cephalic-presenting infant of normal size; 10th-90th birthweight percentile, born at term; 37 to 41 weeks gestation) | G1: 15,974
G1a: cesarean deliveries during labor | | | G1a: N not reported (9.8% of all births)
G1b: cesarean deliveries before labor | | | G1b: N not reported (2.5% of all births)
New South Wales | | | Multiparous:
Low | | | G1: 25,652
| | | G1a: N not reported (3.1% of all births)
| | | G1b: N not reported (8.4% of all births)
| | | Trend: | Before Labor
| | | | Primiparous | | Multiparous
| | | Year | N | % | N | %
| | | 1990 | 15,274 | 2.2 | 25,043 | 8.1
| | | 1991 | 15,617 | 2.1 | 26,698 | 8.2
| | | 1992 | 16,193 | 1.9 | 27,493 | 7.5
| | | 1993 | 15,886 | 2.1 | 26,515 | 7.9
| | | 1994 | 15,959 | 2.3 | 26,745 | 8.0
| | | 1995 | 15,825 | 2.1 | 26,202 | 8.0
| | | 1996 | 15,726 | 2.0 | 25,387 | 8.2
| | | 1997 | 15,974 | 2.5 | 25,652 | 8.4

The most recent figures from these studies indicate rates of all cesarean and elective cesarean delivery of 23.5 percent and 13 percent, respectively, in New South Wales in 2001;^91^ 27.4 percent and 14.1 percent, respectively, in Victoria in 2002;^87^and 30 percent and 13.3 percent, respectively, in South Australia in 2003.^90^

Trend. Trend data was reported on New South Wales,^57,^ ^58,^ ^91^ Victoria,^87^–^89,^ ^92^ and Western Australia.^34^ Studies from the New South Wales database reported nearly constant rates of “elective” cesarean delivery or “cesarean before labor” over a period from 1990 to 1996^57^-1997.^58^ Web-based data for New South Wales from 1996 to 2001 showed a rise in the rate of all cesareans from 17.6 percent to 23.5.^91^ During this period, the rate of “elective” cesareans rose from 9.4 percent to 13.0 percent and the rate of “emergency” cesareans rose from 8.2 percent to 10.5 percent.^91^

Data from Victoria showed a rise in the rate of cesarean deliveries in a 10-year period from 1992 to 2002 from 17.7 percent to 27.4 percent in 2002.^87^–^89,^ ^92^ During this period, the rate of “elective” cesarean delivery rose from 9.7 percent of all deliveries to 14.1 percent and the rate of “emergency” cesarean deliveries rose from 8 percent to 13.3 percent.

One study from Western Australia reported on an earlier time period from 1980 to 1987. The study reported a cesarean delivery rate in 1980 of 11.2 percent; by 1987 it had risen to 16.9 percent.^34^ The rate of “emergency” cesareans rose during this period from 5.8 percent to 8.3 percent; the elective cesarean rate increased from 5.4 percent to 8.7 percent.

The only study reporting rates of primary prelabor cesarean delivery used data from an administrative database from 1980 to 1987 in Western Australia. Using data provided in the publication, we calculated that primary prelabor cesarean deliveries rose from 4.1 percent of all deliveries in 1980 to 4.8 percent in 1987.^34^ More recent data from another study indicate a rate of cesarean before labor of 2.5 percent for primiparous women in 1997 in New South Wales. The authors do not report primary prelabor cesarean rates for multiparous women.

Norway. Incidence. One study of moderate relevance to CDMR reported the rate of “elective” cesarean performed for feto-pelvic disproportion, breech, diabetes, hypertension, pre-eclampsia, twins, and low birthweight as 4.5 percent over a 10-year period (January 1986 to December 1995).^36^ The rate of all cesarean deliveries during this period was 12.5 percent (Table 10).

Table 10 Norway, incidence and trend data

Source | Study Objective | Definitions and Inclusion-Exclusion Criteria | Incidence and Trend Data
Groups | Source
Relevance Rating | Time period
Vangen et. al., 2000^36^ | Objective: to study the prevalences and risk factors for cesarean section among different groups of immigrants in comparison to ethnic Norwegians | Elective: performed for the following reasons: feto-pelvic disproportion, breech, diabetes, hypertension, preeclampsia, twins and low birthweight, and unknown | Incidence
Groups | Retrospective medical birth registry and statistics | Emergent: performed for the following reasons: feto-pelvic disproportion, prolonged labor, fetal distress, breech, diabetes, hypertension, preeclampsia, twins and low birthweight. and unknown | Total births: 553,491
G1: total cesarean delivery | 1/1/1986-12/31/1995 | | N (% of total deliveries)
G1a: elective cesarean delivery | | | G1: 69,249 (12.5%)
Moderate | | | G1a: N not reported (4.5%)
| | | Trend
| | | NR

Denmark. Incidence. The single Danish study reported a total cesarean rate of 11.9 percent and an “unplanned” cesarean rate of 7.7 percent of all deliveries in 1989 (Table 11).^63^ The authors did not comment on planned cesareans, resulting in low relevance to CDMR; we infer that the remainder, that is, 4.2 percent, were planned cesareans.

Table 11 Denmark, incidence and trend data

Source | Study Objective | Definitions and Inclusion-Exclusion Criteria | Incidence and Trend Data
Groups | Source
Relevance Rating | Time period
Lidegaard, et al, 1994^63^ | Objective: to correlate the use of birth-related technologies, the perinatal mortality, and the cesarean delivery rates in Denmark | Labored status and indication not reported | Incidence
Groups | Retrospective survey of maternity ward directors | Publication uses term “unplanned” cesareans | Total births: 179,572
G1: all cesarean deliveries | 1/1/1989-12/31/1989 | Included: births and cesareans after 35 completed weeks of gestation | G1: 11.9% of all deliveries
G1a: unplanned cesarean deliveries | | | G1a: 7.7% of all deliveries
Low | | | Trend
| | | NR

Finland. Incidence. One Finnish study reported a total cesarean rate of 13.9 percent and “elective” cesarean rates of 7.1 percent, as a proportion of all births from July 1985 through June 1986 (Table 12).^62^ The authors did not define elective cesarean delivery resulting in low relevance to CDMR.

Table 12 Finland, incidence and trend data

Source | Study Objective | Definitions and Inclusion-Exclusion Criteria | Incidence and Trend Data
Groups | Source
Relevance Rating | Time period
Jarvelin et al., 1993^62^ | Objective: to examine indications for the induction of labor and variations in the current policy of induction at different levels of obstetric specialization and to compare the outcome of induced and spontaneous labor | Elective: not defined | Total deliveries: 9,362
Groups | Prospective administrative database | | G1: 13.9% of all deliveries
G1: all cesarean deliveries | 7/1/1985-6/30/1986 | | G1a: 7.1% of all deliveries
G1a: elective cesarean delivery
Low

## Key Question 2: Outcomes of Cesarean Delivery on Maternal Request

As noted in Chapter 1, planned cesarean or planned vaginal delivery each have a range of numerous possible endpoints. Table 13 lists such endpoints for planned cesarean deliveries and for planned vaginal deliveries, noting the relevance to CDMR (ratings of high, moderate, or low, and, by definition, not applicable [NA] for vaginal deliveries).

Table 13 Possible endpoints from planned route of delivery and relevance as proxies to CDMR

Possible Endpoints from Planned Cesarean Delivery | Relevance as Proxies to CDMR
Planned cesarean delivery on maternal request (no maternal or neonatal indications) | High
Trial of cesarean for specific indications such as breech | Moderate
Planned cesarean performed for neonatal indications (unlabored) | Moderate
Cesarean planned and performed for maternal indications, unlabored | Moderate
Cesarean planned and performed for neonatal or maternal indications, unlabored | Moderate
Cesarean planned and performed but presented in labor for neonatal indications | Moderate
Cesarean planned and performed but presented in labor for maternal indications | Moderate
Cesarean planned and performed but presented in labor for neonatal or maternal indications | Moderate
Cesarean planned and performed but mix of labor and unlabored for neonatal indications | Moderate
Cesarean planned and performed but mix of labor and unlabored for maternal indications | Moderate
Cesarean planned and performed but mix of labor and unlabored for neonatal or maternal indications | Moderate
Mix of planned and unplanned cesarean, unlabored, for maternal or neonatal indications | Low
Planned cesarean unspecified as to indications or labor /“elective” unspecified as to indications or labor | Low
Possible Endpoints from Planned Vaginal Delivery
Trial of vaginal delivery for specific indications such as breech | NA*
Spontaneous vaginal delivery | NA
Vacuum | NA
Forceps | NA
Vacuum and/or forceps | NA
Mix of spontaneous and assisted vaginal deliveries | NA
Vaginal unspecified | NA
Unplanned unlabored cesarean for neonatal indications | NA
Unplanned unlabored cesarean for maternal indications | NA
Unplanned unlabored cesarean for neonatal or maternal indications | NA
Unplanned labored cesarean for neonatal indications | NA
Unplanned labored cesarean for maternal indications | NA
Unplanned labored cesarean for neonatal or maternal indications | NA
Unplanned mix of labored and unlabored cesarean for neonatal indications | NA
Unplanned mix of labored and unlabored cesarean for maternal indications | NA
Unplanned mix of labored and unlabored cesarean for neonatal or maternal indications | NA
Unplanned cesarean unspecified or “emergency” | NA

* NA, not applicable

We present three tables to summarize the literature with reference to their particular study populations, relevance, and outcomes. Table 14 presents actual comparison groups for each study and the associated relevance rating. Table 15 catalogs the maternal and neonatal outcomes pertinent to this review that appeared in each study. Table 16 lists confounders, specifically preterm deliveries, placental previa, multiple gestations, and multiparity, for each study.

Table 14 Comparison groups

| | Study and Population Characteristics
Source | Relevance Rating* | Planned Route of Delivery | Planned Cesarean Delivery (CD) | | | | | Mix of Planned and Unplanned CD | “Elective” Unspecified | Planned Vaginal Delivery (VD) | Unspecified, Planned VD Assumed | | | | | Planned VD | | | | | Mix of planned and unplanned vaginal delivery
| | Analyzed by planned (P) or actual (A) delivery | P | A | A | A | A | A | A | P | A | A | A | A | A | A | A | A | A | A | A | A
| | Labored (L) or unlabored (UL) | Both | UL | L | Both | Both | UL | NR | Both | L | L | L | L | L | L | UL | L | Both | NR or “Emergency” | L | Both
| | Indications for cesarean delivery (mat, fet, both) | Both | Both | Both | Mat | Both | Both | NR | Both | NA | NA | NA | NA | NA | NA | Both | Both | Both | Both | Both | Both
| | Actual route of delivery (CD, VD) | CD and VD | CD | CD | CD | CD | CD | CD | CD and VD | SVD | VAVD | FAVD | VAVD and/or FAVD | SVD and AVD | Unspecified VD | CD | CD | CD | CD | CD | CD
Hannah et al., 2002^18^ | T | | • | | | | | | | •
Hannah et al., 2004^83^ | T | | • | | | | | | | •
Hannah et al., 2000^20^ | T | | • | | | | | | | •
Leiberman et al., 1995^84^ | T | | • | | | | | | | •
Badawi et al., 1998^37^ | M | | | | | | • | | | | • | | | • | | | | • | | •
Burrows et al., 2004^39^ | M | | | • | | | | | | | • | | | • | | | | | | •
Bergholt et al., 2003^38^ | M | | | | | | • | | | | | | | | | | | | •
Dessole et al., 2004^40^ | M | | | • | • | | | | | | | | | | | | | | •
Farrell et al., 2001^41^ | M | | | • | | | | | | | • | | • | | | | | | | | •
Farrell et al., 2001^42^ | M | | | • | | | | | | | • | | • | | | | | | | | •
Fawcett et al., 1992^43^ | M | | | | | | • | | | | | | | | | | | | • | •
Groutz et al., 2004^44^ | M | | | | | • | | | | | • | | | | | | | •
Hillan, 1995^45^ | M | | | • | | | | | | | | | | | | | • | •
Lal et al., 2003^46^ | M | | | • | | | | | | | • | | | | | | | | •
Levine et al., 2001^47^ | M | | | • | | | | | | | | | | | | • | | | | | | •
Morrison et al., 1995^48^ | M | | | | | | • | | | | | | | | • | | | •
Nice et al., 1996^49^ | M | | | | | | • | | | | | | | | | | | | •
Sanchez-Ramos et al., 2001^50^ | M | | | | | | • | | | •
Schindl et al., 2003^51^ | M | | | | | | • | | | † | | | | | | • | | | | •
van Ham et al., 1997^28^ | M | | | • | | | | | | | | | | | | | | • | •
Zanardo et al., 2004^52^ | M | | | | | | • | | | | | | | | | •
Zanardo et al., 2004^53^ | M | | | | | | • | | | | | | | | | •
Allen et al., 2003^64^ | L | | | | | | | • | | | • | | | • | | | | | | | •
Dani et al., 1999^65^ | L | | | | | | | | • | | • | | | • | | | | | | •
Durik et al., 2000^66^ | L | | | | | | | | • | | | | | | | • | | | | •
Golfier et al., 2001^67^ | L | | | | | | | | • | •
Irion et al., 1998^68^ | L | | | | | | | | • | •
Koroukian, 2004^69^ | L | | | | | | | | • | | • | | | • | | | | | | •
Krebs and Langhoff-Roos, 2003^70^ | L | | | | | | | • | | | | | | | | | | | | | •
MacArthur et al., 2001^72^ | L | | | | | | | | • | | • | • | • | | | | | | | •
MacArthur et al., 1997^71^ | L | | | | | | | | • | | • | • | • | | • | | | | | •
Mason et al., 1999^73^ | L | | | | | | | | • | | • | • | • | | | | | | | •
Persson et al., 2000^74^ | L | | | | | | | | • | | • | | | | | | | | | | | •
Phipps et al., 2005^75^ | L | | | | | | | | • | | | | | | | | | | | •
Reichert et al., 1993^76^ | L | | | | | | | | • | | | | | | | | | | | •
Rubaltelli et al., 1998^77^ | L | | | | | | | | • | | | | | | | | | | | •
Ryding et al., 1998^78^ | L | | | | | | | | • | | • | | | • | • | | | | | •
Schytt et al., 2004^79^ | L | | | | | | | | • | | • | | | • | | | | | | •
Sutton et al., 2001^80^ | L | | | | | | | • | | | | | • | | | • | | | | | •
Towner et al., 1999^81^ | L | | | | | | | • | | | • | • | • | • | | | | | | | •
Wilson et al., 1996^82^ | L | | | | | | | | • | | • | | • | | | | | | | •

Table 15 Maternal and neonatal outcomes reported

Outcomes | | Maternal Outcomes Relevant to Primary CDM | | | | | | | | | | | | | | | | Maternal Outcomes Relevant to Subsequent Cesarean Delivery | | | Neonatal Outcomes
| Relevance rating | Mortality | infection | Anesthetic complications | Hemorrhage/blood transfusion | Hysterectomy | Thromboembolism | Surgical complications | Breastfeeding | Postpartum pain | Psychological outcomes (postpartum depression) | Psychological outcomes (other) | Maternal length of stay | Urinary incontinence | Anorectal function | Pelvic organ prolapse | Sexual function | Subsequent fertility issues | Subsequent uterine rupture | Subsequent stillbirth | Fetal mortality | Neonatal mortality | Unexpected (iatrogenic) prematurity | Respiratory morbidity | Transition | Neonatal asphyxia/encephalopathy | Intracranial hemorrhage | Facial nerve injury | Brachial plexus injury | Fetal laceration | Neonatal length of stay | Longterm outcomes
Hannah et al., 2002^18^ | T | | | | | | | | • | • | • | • | | • | • | | •
Hannah et al., 2004^83^ | T | | | | | | | | • | • | • | • | | • | • | | •
Hannah et al., 2000^20^ | T | • | • | | • | • | • | | | | • | • | •
Leiberman et al., 1995^84^ | T | | • | | | | •
Badawi et al., 1998^37^ | M | | | | | | | | | | | | | | | | | | | | | | | | | •
Bergholt et al., 2003^38^ | M | | | | • | • | | • | | | | | | | | | | | •
Burrows et al., 2004^39^ | M | | • | | • | | •
Dessole et al., 2004^40^ | M | | | | | | | | | | | | | | | | | | | | | | | | | | | | | •
Farrell et al., 2001^41^ | M | | | | | | | | | | | | | •
Farrell et al., 2001^42^ | M | | | | | | | | | | | | | | •
Fawcett et al., 1992^43^ | M | | | | | | | | | • | | • | •
Groutz et al., 2004^44^ | M | | | | | | | | | | | | | •
Hillan et al., 1995^45^ | M | | • | | •
Lal et al., 2003^46^ | M | | | | | | | | | | | | | | •
Levine et al., 2001^47^ | M | | | | | | | | | | | | | | | | | | | | | | | •
Morrison et al., 1995^48^ | M | | | | | | | | | | | | | | | | | | | | | | | •
Nice et al., 1996^49^ | M | | •
Sanchez-Ramos et al., 2001^50^ | M | | | • | • | | | | | | | | •
Schindl et al., 2003^51^ | M | | • | • | • | | | • | | • | | • | | | | | | | | | | | | •
van Ham et al., 1997^28^ | M | • | • | | • | | • | • | | | | | • | | | | | | | | | | | | | | | | | •
Zanardo et al., 2004^52^ | M | | | | | | | | | | | | | | | | | | | | | | | • | | | | | | | •
Zanardo et al., 2004^53^ | M | | | | | | | | | | | | | | | | | | | | | • | | • | | | | | | | •
Allen et al., 2003^64^ | L | • | • | | • | | | •
Dani et al., 1999^65^ | L | | | | | | | | | | | | | | | | | | | | | | | •
Durik et al., 2000^66^ | L | | | | | | | | | | • | •
Golfier et al., 2001^67^ | L | | • | | • | | • | •
Irion et al., 1998^68^ | L | | • | | • | • | • | •
Koroukian, 2004^69^ | L | | • | • | • | | • | •
Krebs and Langhoff-Roos, 2003^70^ | L | • | • | | | | • | • | | | | | | • | • | • | | • | | •
MacArthur et al., 2001^72^ | L | | | | | | | | | | | | | | •
MacArthur et al., 1997^71^ | L | | | | | | | | | | | | | | •
Mason et al., 1999^73^ | L | | | | | | | | | | | | | •
Persson et al., 2000^74^ | L | | | | | | | | | | | | | •
Phipps et al., 2005^75^ | L | | | | | | | •
Reichert et al., 1993^76^ | L | | | | | | | | | | | •
Rubaltelli et al., 1998^77^ | L | | | | | | | | | | | | | | | | | | | | | | | •
Ryding et al., 1998^78^ | L | | | | | | | | | | | •
Schytt et al., 2004^79^ | L | | | | | | | | | | | | | •
Sutton et al., 2001^80^ | L | | | | | | | | | | | | | | | | | | | | | | | •
Towner et al., 1999^81^ | L | | | | | | | | | | | | | | | | | | | | | • | | • | • | • | • | • | •
Wilson et al., 1996^82^ | L | | | | | | | | | | | | | •

Table 16 Inclusion of possible confounders

| Relevance Rating | Nulliparous Only | Includes Preterm | Includes Previa | Includes Repeat Cesarean Delivery | Includes Multiple Gestations
Hannah et al., 2000^20^ | T | No | No | No | Yes | No
Hannah et al., 2002^18^ | T | No | No | No | Yes | No
Hannah et al., 2004^83^ | T | No | No | No | Yes | No
Leiberman et al., 1995^84^ | T | Yes | No | Yes | No | No
Badawi et al., 1998^37^ | M | No | No | Yes | Yes | Unspecified
Bergholt et al., 2003^38^ | M | No | Yes | Yes | Yes | Yes
Burrows et al., 2004^39^ | M | No | No | Unspecified | Yes | No
Dessole et al., 2004^40^ | M | No | Yes | Yes | Yes | Yes
Farrell et al., 2001^41^ | M | Yes | Probably | Unspecified | No | Unspecified
Farrell et al., 2001^42^ | M | Yes | Probably | Unspecified | No | Unspecified
Fawcett et al., 1992^43^ | M | No | No | Probably | Yes | Unspecified
Groutz et al., 2004^44^ | M | Yes | No | No | No | Unspecified
Hillan, 1995^45^ | M | No | Probably | Probably | Probably | Probably
Lal et al., 2003^46^ | M | Yes | Yes | Unspecified | No | No
Levine et al., 2001^47^ | M | No | Yes (≥35 wks) | Yes | Yes | Yes
Morrison et al., 1995^48^ | M | No | No | Probably | Probably | Unspecified
Nice et al., 1996^49^ | M | No | Probably | Probably | Probably | Probably
Sanchez-Ramos et al., 2001^50^ | M | No | Yes (≥35 wks) | Unspecified | Yes | No
Schindl et al., 2003^51^ | M | No | No | Probably | Yes | Yes
van Ham et al., 1997^28^ | M | No | Yes | Yes | Yes | Probably
Zanardo et al., 2004^52^ | M | No | No | Yes | Yes | Yes
Zanardo et al., 2004^53^ | M | No | No | Yes | Yes | Yes
Allen et al., 2003^64^ | L | Yes | No | Unspecified | No | No
Dani et al., 1999^65^ | L | No | Yes | Yes | Probably | Yes
Durik et al., 2000^66^ | L | No | Probably | Probably | Probably | Probably
Golfier et al., 2001^67^ | L | No | No | Unspecified | Probably | No
Irion et al., 1998^68^ | L | No | Yes (≥36 wks) | No | Probably | No
Koroukian, 2004^69^ | L | No | No | No | Probably | No
Krebs and Langhoff-Roos, 2003^70^ | L | Yes | Yes | Unspecified | No | No
MacArthur et al., 2001^72^ | L | No | Probably | Unspecified | Probably | Unspecified
MacArthur et al., 1997^71^ | L | No | Probably | Probably | Probably | Unspecified
Mason et al., 1999^73^ | L | No | Probably | Probably | Probably | Probably
Persson et al., 2000^74^ | L | No | Probably | Probably | Probably | Yes
Phipps et al., 2005^75^ | L | No | Yes | Probably | Yes | Probably
Reichert et al., 1993^76^ | L | No | No | Yes | Yes | Unspecified
Rubaltelli et al., 1998^77^ | L | No | Yes | Yes | Probably | Yes
Ryding et al., 1998^78^ | L | No | Probably | Probably | Probably | Unspecified
Schytt et al., 2004^79^ | L | No | Probably | Probably | Yes | No
Sutton et al., 2001^80^ | L | No | No | Probably | Probably | No
Towner et al., 1999^81^ | L | Yes | Probably | Probably | No | No
Wilson et al., 1996^82^ | L | No | No | Probably | Yes | Yes

T, trial of planned route of delivery; M, moderate; L, low.

The underlying concerns for the SOS conference relate to maternal and neonatal outcomes, as depicted in the analytic framework of Chapter 1 (Figure 3). This section presents results for maternal outcomes for primary cesarean deliveries as directed by the SOS Conference panel chair and in consultation with the Technical Expert Panel (TEP). Our systematic search strategies focused on primary cesarean delivery, however, we provide a summary of outcomes particularly relevant to subsequent cesarean deliveries such as subsequent uterine rupture, placenta previa, and subsequent stillbirth. We conclude this section with a summary of results for neonatal outcomes.

We organized maternal outcomes by proximity to the delivery and then, generally, by severity of the outcome. Maternal outcomes related to pelvic floor disorder, urinary incontinence, pelvic organ prolapse, and fecal incontinence appear last. Neonatal outcomes are similarly listed by proximity to delivery and severity of outcome.

We present results for each outcome by relevance to CDMR. With respect to the quality of individual studies, we then examine studies rated “T” and the studies judged to be moderately relevant for quality (categorized as good, fair, or poor). We had no highly relevant studies for this question, and we did not grade low relevance studies for quality because we believed such grading would be unfair to studies that were obviously designed and conducted for other purposes. Thus, we focus mainly on studies of moderate relevance graded either good or fair quality; we only summarize information from poor studies (regardless of relevance) or those of low relevance (regardless of quality).

Below we present a general discussion of the direction of evidence in the following text for outcomes with more than three studies; summary tables document specific results. Because of the extreme range and diversity of outcome measures, reference groups used for comparisons, methods for reporting data, and statistical tests used, these tables are necessarily complex. We focus on percentages of women with the outcome in question in the various cesarean and vaginal delivery groups, significance of any results, and (when provided) odds ratios (OR) or relative risks (RR) provided by study authors. We do not present summary tables for outcomes with three or fewer studies; those results are noted only in text.

Finally, we do not have summary tables on psychological outcomes for two reasons. First, these outcomes had not been specified as being of high priority for the SOS conference, and time and resource constraints led us to focus on SOS-priority outcomes. Second, psychological outcomes were so numerous and varied that presenting them in summary tables seemed impractical. Where appropriate, we have reported or commented on these outcomes in the text below.

### Maternal Outcomes for Primary Cesarean Deliveries

The following outcomes are relevant to both primary and subsequent cesarean deliveries. However, we draw upon evidence from studies focusing on primary cesarean deliveries to address the maternal outcomes listed below. As noted in Table 16, some of these studies include repeat cesarean deliveries. However, no study included in this review is limited to repeat cesareans. Outcomes particularly relevant to subsequent cesarean deliveries are addressed in the next section.

Mortality. Four studies reported on maternal mortality associated with mode of delivery (Table 17).^20,^ ^28,^ ^64,^ ^70^ One is the randomized Breech Trial (relevance rating of T); we gave the initial report a quality rating of fair. This trial compared planned vaginal with planned cesarean for breech and analyzed results using intent-to-treat.^20^ We rated another study as moderately relevant but of poor quality.^28^ We rated the two remaining studies as having low relevance and did not rate quality.^64,^ ^70^

Table 17 Mortality

Author, Year | Measure | Outcomes for Comparison Groups | | | | Statistical Test Results
Relevance/Quality Rating
Hannah et al., 2000^20^ | | Planned CD | Planned VD
T/Fair | Mortality | 0 | 0.1% | | | NR
van Ham et al., 1997^28^ | | Primary Elective CD | Primary Acute CD | Secondary Acute CD
Moderate/Poor | Mortality | 3 cases of mortality due to underlying pathology, NR by category | | | | NR
Allen et al., 2003^64^ | | Elective CD | SVD | AVD | CD in labor
Low/Not rated | Mortality | 0 | 0 | 0 | 0 | NR
Krebs et al., 2003^70^ | | Elective CD | VD | Emergency CD
Low/Not rated | Mortality | None of the 83 deaths reported in the sample of 15,441 women were associated with mode of delivery | | | | NR

CD, cesarean delivery; VD, vaginal delivery; SVD, spontaneous vaginal delivery; AVD, assisted vaginal delivery; NR, not reported.

The Breech Trial initially reported one death in the planned vaginal group (n = 1,042, or 0.1%), and none in the planned cesarean group (n = 1,041).^20^ The patient who died was described as “jaundiced before labor, developed disseminated intravascular coagulation after delivery, and died of hepatorenal failure at 44 hours postpartum” (p. 1380).^20^

The moderately relevant (poor) study identified three maternal deaths that had been caused by underlying pathology.^28^ The authors did not characterize these cases as either labored or unlabored cesarean deliveries, nor did they comment on indication for cesarean; thus, this study provides little information relevant to CDMR.

Of the two low relevance studies, one study reported some deaths but none associated with mode of delivery,^70^ and the other reported no maternal deaths at all.^64^

Infection. Twelve studies^20,^ ^28,^ ^39,^ ^45,^ ^49,^ ^51,^ ^64,^ ^67^–^70,^ ^84^ included maternal infection as an outcome (Table 18).

Table 18 Infection

Author, Year | Measure | Outcomes for Comparison Groups | | | | | | Statistical Test Results
Relevance/Quality Rating
Hannah et al., 2000^20^ | | Planned CD | Planned VD
T/Fair | Wound infection | 1.5% | 1.0% | | | | | P = 0.32
| Maternal systemic infection | 1.5% | 1.3% | | | | | P = 0.71
Burrows et al., 2004^39^ | | Primary Prelabor CD | Repeat Prelabor CD | Primary Labored CD | Repeat Labored CD | SVD (ref grp) | Operative VD
Moderate/Fair | Endometritis | 3.0% | 2.7% | 9.4% | 4.6% | 0.4% | 0.7% | Significantly different for all other than operative VD
| Adj OR (95% CI) | 10.3 (5.9; 17.9) | 9.9 (5.8; 16.9) | 21.2 (15.4; 29.1) | 14.6 (9.2; 23.1) | 1.0 | 0.9 (0.6; 1.5)
| Pneumonia | 0.3% | 0.5% | 0.1% | 0.7% | 0.1% | 0.2% | Significantly different for all other than operative VD and primary labored CD
| Adj OR (95% CI) | 4.7 (1.1; 20.4) | 5.2 (1.5; 18.1) | 1.7 (0.6; 5.2) | 9.3 (3.4; 25.6) | 1.0 | 2.3 (1.0; 5.4)
Leiberman et al., 1995^84^ | | Planned CD | Planned Trial of Labor (ref grp)
T/Fair | Combined measure of maternal morbidity (includes febrile morbidity, endometritis, wound infection, UTI and thrombophlebitis) | 31.0% | 17.8%
| OR (95% CI) | 0.48 (0.25; 0.89) | 1.0
Hillan, 1995^45^ | | Elective CD | Emergency CD
Moderate/Poor | UTI | 10.9% | 10.3% | | | | | P NS
| Wound infection | 4.1% | 8.3% | | | | | P < 0.05
| Pelvic infection (intrauterine) | 1.4% | 6.0% | | | | | P < 0.01
Nice et al., 1996^49^ | | Elective CD | Emergency CD
Moderate/Nice | Wound infection | 6.4% | 7.6% | | | | | NS, statistics NR
Schindl et al., 2003^51^ | | Elective CD | Emergency CD
Moderate/Fair | Sepsis | 0 | 0.1%
van Ham et al., 1997^28^ | | Primary Elective CD | Primary Acute CD | Secondary Acute CD
Moderate/Poor | UTI | 2.5% | 3.4% | 3.1% | | | | NS, statistics NR
| Wound infection | 1.0% | 1.7% | 2.8% | | | | NS, statistics NR
| Endometritis | 1.3% | 0.5% | 1.6% | | | | NS, statistics NR
| Pelvic infection (intrauterine) | 0.6% | 0.1% | 1.0% | | | | NS, statistics NR
| Sepsis | 0 | 0.6% | 0.2% | | | | NS, statistics NR
| Pneumonia | 0 | 0.6% | 0.4% | | | | NS, statistics NR
Allen et al., 2003^64^ | | Elective CD | SVD (ref grp) | AVD (ref grp) | CD in Labor (ref grp)
Low/Not rated | Wound infection | 1.5% | 0.4% | 2.0% | 2.2% | | | P < 0.001
| | RR vs SVD: 3.5 (1.8, 6.7);
| | RR vs AVD: 0.8 (0.4, 1.5);
| | RR vs CD in labor: 0.7 (0.4, 1.4)
Golfier et al., 2001^67^ | | Elective CD | Planned VD (ref grp)
Low/Not rated | Moderate and severe complications | 6.0% | 5.8% | | | | | NS
| RR (95% CI) | 0.97 (0.59; 1.57) | 1.0
| Mild complications | 6.7% | 2.4% | | | | | Significantly different
| RR (95% CI) | 0.46 (0.24; 0.9) | 1.0
Irion et al., 1998^68^ | | Elective CD (ref grp) | Attempted VD
Low/Not rated | UTI | 12.5% | 5.2% | | | | | P < 0.001
| RR (95% CI) | 1.0 | 0.42 (0.25; 0.70)
| Endometritis | 4.1% | 1.8% | | | | | P = 0.07
| RR (95% CI) | 1.0 | 0.45 (0.18; 1.11)
| Pneumonia | 0.3% | 0.8% | | | | | P = 0.63
| RR (95% CI) | 1.0 | 2.49 (0.26; 23.86)
Koroukian, 2004^69^ | | Elective CD | SVD | AVD | Non-elective CD
Low/Not rated | Major puerperal infection in entire sample | 2.9% | 0.9% | 1.1% | 4.3% | | | Significantly different
| | Elective CD | Uncomplicated SVD (ref grp)
| Major puerperal infection in subset of uncomplicated deliveries | 2.9% | 0.8% | | | | | Significantly different
| RR (95% CI) | 3.75 (3.12; 4.51) | 1.0
Krebs and Langhoff-Roos, 2003^70^ | | Elective CD | VD (ref grp) | Emergency CD (ref grp)
Low/Not rated | Puerperal fever/pelvic infection | 1.5% | 0.5% | 2.3% | | | | Significantly different
| | RR vs VD: 1.2 (1.11; 1.25);
| | RR vs Emergency CD: 0.81 (0.7; 0.92)
| Wound infection | 0.9% | 0.7% | 1.8% | | | | Significantly different
| | RR vs VD: NR; Emergency CD: 0.69 (0.57; 0.83)

UTI, urinary tract infection; CD, cesarean delivery; SVD, spontaneous vaginal delivery; AVD, assisted vaginal delivery; ref grp, reference group; NS, not significant; NR, not reported; Adj, adjusted; OR, odds ratio; RR, risk ratio; CI, confidence interval.

The Breech Trial found no significant differences in the rates of wound infection or maternal systemic infection.^20^ An earlier nonrandomized study (rated fair) compared a trial of planned vaginal with planned cesarean for breech and analyzed results using intent-to-treat. The investigators used a composite measure of maternal morbidity (febrile morbidity, endometritis, wound infection, urinary tract infection [UTI], and thrombophlebitis) and determined that it was significantly higher in the planned cesarean group.^84^

Of five moderately relevant studies, two were of fair quality,^39,^ ^51^ and three were of poor quality.^28,^ ^45,^ ^49^ Only one of these compared planned “intended” vaginal delivery with planned “elective” cesarean delivery.^51^ It did not give a detailed assessment of maternal infection beyond reporting a single case of sepsis among the 903 intended vaginal births and none among the 147 “elective” cesarean births.

Three studies compared outcomes only between various types of cesarean delivery; this restriction limited their utility for addressing the maternal infection issue in terms of planned CDMR vs. planned vaginal delivery. Of these, one study found no difference in UTI between planned “elective” and unplanned “emergency” cesarean deliveries but did find significantly lower rates of wound, intrauterine, and chest infections in the planned “elective” cesarean group.^45^ The second reported no significant difference in the rate of UTI, wound infection, and endometritis between planned “elective” cesarean and unplanned “acute” and “secondary acute” cesarean deliveries.^28^ The third set of investigators limited their analysis to wound infection and distinguished between major and minor infections. However, they did not provide a statistical comparison of wound infection rates between planned “elective” and unplanned “emergency” cesarean deliveries.^49^

The most recent moderately relevant study compared various actual modes of delivery.^39^ The risk of endometritis was significantly higher for both planned “without trial of labor” and unplanned “with trial of labor” primary cesarean deliveries than for spontaneous vaginal delivery. The risk of pneumonia was higher for both types of cesareans but significantly higher only for the planned “without trial of labor” primary cesarean group.

The remaining five studies were of low relevance because the authors either combined planned and unplanned cesareans in their cesarean comparison groups^64,^ ^70^ or did not define “elective” cesarean delivery.^67^–^69^ Generally, these studies found that the risk of maternal infection was lower for planned “elective” cesarean than for unplanned or labored or “emergency” cesarean but lower for vaginal delivery than for planned “elective” cesarean.

Anesthetic complications. Of three studies reporting on anesthetic complications associated with mode of delivery, two were moderately relevant to CDMR^50,^ ^51^ and one was of low relevance.^69^

One moderately relevant study (fair quality) reported a 4 percent rate of problems with “peridural” anesthesia/postspinal headache in the “elective” cesarean group (6 of 147 women) and a 2 percent rate (18 of 903 women) with an intended vaginal birth;^51^ the authors did not provide statistical testing for this outcome. The other study (poor quality) reported no difference in anesthetic complications between planned cesarean and planned vaginal delivery.^50^

The low relevance study obtained data from an administrative database using International Classification of Diseases, ninth edition (ICD-9) codes and reported rates of anesthetic complications in ascending order per 1,000 women: spontaneous vaginal deliveries, 90; assisted vaginal deliveries, 160; unplanned “nonelective” cesarean deliveries, 360; and planned “elective” cesarean deliveries, 390.^69^

Hemorrhage/blood transfusion. Of the 11 articles (Table 19) that evaluated blood loss associated with route of delivery, 1 was from the Breech Trial,^20^ 6 were moderately relevant,^28,^ ^38,^ ^39,^ ^45,^ ^50,^ ^51^ and four were of low relevance.^64,^ ^67^–^69^

Table 19 Hemorrhage

Author, Year | Measure | Outcomes for Comparison Groups | | | | | | Statistical Test Results
Relevance/Quality Rating
Hannah et al., 2000^20^ | | Planned CD | Planned VD
T/Fair | Postpartum bleeding | 1.0% | 1.3% | | | | | P = 0.68
| Hemorrhage > 1,000 ml | 0.4% | 0.8% | | | | | NR
| Hemorrhage> 1,500 ml | 0.2% | 0.4% | | | | | NR
| Hemorrhage requiring transfusion | 0.4% | 0.8% | | | | | NR
| Hemorrhage requiring D&C | 0.3% | 0.4% | | | | | NR
| Other hemorrhage | 0.2% | 0.1% | | | | | NR
Burrows et al., 2004^39^ | | Primary Prelabor CD | Repeat Prelabor CD | Primary Labored CD | Repeat Labored CD | SVD (ref grp) | Operative VD
Moderate/Fair | Postpartum hemorrhage | 2.7% | 3.2% | 3.9% | 2.6% | 5.0% | 4.7% | Labored CD and operative VD significantly different from SVD
| Adj OR (95% CI) | 0.7 (0.4; 1.1) | 0.8 (0.6; 1.2) | 0.8 (0.6; 0.9) | 0.6 (0.4; 0.96) | 1.0 | 0.8 (0.7; 0.97)
| Transfusion | 0.3% | 0.5% | 1.1 | 0.8% | 0.2% | 0.4% | All modes of delivery other than primary prelabor CD are significantly different from SVD
| Adj OR (95% CI) | 2.6 (0.8; 8.5) | 3.0 (1.1; 8.3) | 4.4 (2.7; 7.1) | 4.2 (1.8; 10.1) | 1.0 | 2.2 (1.3; 3.7)
Bergholt et al., 2003^38^ | | Elective CD | Emergency CD
Moderate/Fair | Blood transfusion | 0.7% | 1.1% | | | | | NS
| Estimated blood loss ≥ 1,000 ml | 6.8% | 9.0% | | | | | NS
| Risk of intraoperative blood loss ≥ 1,000 ml during the cesarean delivery from emergency c/s | NA | Crude OR: 1.3 Adjusted OR: 1.6 (0.7; 3.4)
Hillan, 1995^45^ | | Elective CD | Emergency CD
Moderate/Poor | Blood transfusion | 1.4% | 4.5% | | | | | P < 0.05
Sanchez-Ramos et al., 2001^50^ | | Elective CD | Attempted Vaginal Breech
Moderate/Poor | Hemorrhage | 1.0% | 1.1% | | | | | P = 1.00
Schindl et al., 2003^51^ | | Elective CD | Intended VD
Moderate/Fair | Blood transfusion | 0 | 0.6% | | | | | NR
| Sepsis | 0 | 0.1% | | | | | NR
van Ham et al., 1997^28^ | | Primary Elective CD | Primary Acute CD | Secondary Acute CD
Moderate/Poor | Blood loss (intraoperative) | 4.7% | 7.8% | 8.7% | | | | P < 0.001
| Blood loss (post-operational) ≥ 1,500 ml | 1.5% | 2.9% | 2.6% | | | | NR
| Blood loss (post-operational) 1,000 to 1,500 ml | 2.8% | 3.7% | 4.9% | | | | NR
Allen et al., 2003^64^ | | Elective CD (ref grp) | SVD | AVD | CD in Labor
Low/Not rated | Blood transfusion | 0.3% | 0.3% | 0.8% | 0.5%
| RR (95% CI) | 1.0 | 0.9 (0.2; 3.8) | 0.4 (0.1; 1.6) | 0.5 (0.1; 2.4) | | | SVD significantly different than elective CD
| Early postpartum hemorrhage | 3.8% | 5.1% | 9.6% | 7.5% | | | P < 0.001
| RR (95% CI) | 1.0 | 0.8 (0.5; 1.1) | 0.4 (0.3; 0.6) | 0.5 (0.4; 0.8) | | | AVD and CD in labor significantly different than elective CD
Golfier et al., 2001^67^ | | Elective CD | Planned VD
Low/Not rated | Blood transfusion | 0.3% | 1.0% | | | | | NR
Irion et al., 1998^68^ | | Elective CD | Attempted VD
Low/Not rated | Hysterectomy for hemorrhage | 0.3% | 0 | | | | | P = 0.45
Koroukian, 2004^69^ | | Elective CD | SVD | AVD | Nonelective CD
Low/Not rated | Postpartum hemorrhage in entire sample | 1.74% | 3.0% | 3.13% | 2.22%
| | Elective CD | Uncomplicated SVD (ref grp)
| Postpartum hemorrhage in subset of uncomplicated deliveries | 1.74% | 2.42% | 3.0% | | | | Significantly different
| RR (95% CI) | 0.60 (0.48; 0.76) | 1.0
| Blood transfusion in entire sample | Elective CD | SVD | AVD | Nonelective CD
| | 0.07% | 0.11% | 0.12% | 0.37%
| | Elective CD | Uncomplicated SVD (ref grp)
| Blood transfusion in subset of uncomplicated deliveries | 0.07% | 0.06% | | | | | Not signficantly different
| RR (95% CI) | 1.16 (0.41; 3.25) | 1.0

Adj, Adjusted; AVD, assisted vaginal delivery; CD, cesarean delivery; CI, confidence interval; SVD, spontaneous vaginal delivery; ref grp, reference group; NS, not significant; NR, not reported; NA, not applicable; OR, odds ratio; RR, relative risk; VD, vaginal delivery.

As with other outcomes, definitions were not standardized. We encountered various measures of hemorrhage: blood loss >1,000 ml, blood loss >1,500 ml, blood transfusion, need for dilatation and curettage, and undefined postpartum hemorrhage. We chose to report these clinically relevant outcomes rather than anemia (change in hemoglobin or hematocrit level).

The Breech Trial (fair quality) included a heterogeneous group of women: women who were multiparous, had a history of a previous cesarean, and presented in labor.^20^ The planned cesarean group had lower rates of postpartum bleeding (1.0%)—defined as estimated blood loss (EBL) >1,000ml, EBL >1,500ml, blood transfusion or need for dilatation and curettage—than the planned vaginal delivery group (1.3%); the difference was not statistically significant.

Five of the six moderately relevant studies limited comparisons to only planned “elective” vs. unplanned “emergency” cesarean delivery; they defined significant blood loss as blood loss >1000 ml,^28^ transfusion,^45,^ ^50,^ ^51^ or both.^38^ Of these five, two were of fair quality^51 38^and three were of poor quality.^28,^ ^45,^ ^50^ The sixth study (fair quality) identified postpartum hemorrhage and transfusion through ICD-9 codes and reported these outcomes separately.^39^

Of all six studies, five showed a lower risk of major blood loss with planned “elective” than with unplanned “emergency” cesarean delivery.^28,^ ^38,^ ^39,^ ^45,^ ^51^ The differences were statistically significant in two studies (both poor).^28,^ ^45^

The three moderately relevant studies that compared risk of blood transfusion differed in their comparison groups. One showed a nonsignificant higher absolute risk with planned cesarean (1.1 percent) than with unplanned cesarean (0.7 percent).^38^ A second reported cases of blood transfusions in only the planned vaginal delivery group but provided no statistical testing.^51^ The third study found a higher risk of blood transfusion with both unplanned “with trial of labor” and planned “without trial of labor” primary cesareans than with spontaneous vaginal deliveries. The higher risk was statistically significant only in the unplanned “with trial of labor” group.^39^

In the only study that did not report a lower rate of blood loss associated with elective cesarean birth,^50^ the rates of blood transfusion were similar between elective cesarean and planned vaginal delivery: 1.2 percent vs. 1.1 percent, respectively.

Of the four studies of low relevance, three defined significant blood loss as requiring a blood transfusion;^64,^ ^67,^ ^69^ planned “elective” cesarean was associated with a lower rate of blood transfusion than that for planned vaginal delivery. Of these three studies, two compared planned “elective” cesarean with spontaneous vaginal, assisted vaginal, and unplanned “nonelective” cesarean or cesarean in labor.^64,^ ^69^ In both studies, assisted vaginal delivery and nonelective or labored cesarean had the highest rates of blood transfusions. These results were statistically significant in only one study, which reported an absolute risk reduction for blood transfusion per 1,000 deliveries of 3.7 for nonelective cesarean, 1.2 for assisted vaginal, 1.1 for spontaneous vaginal, and 0.7 for elective cesarean delivery.^69^ Other analyses comparing elective cesarean sections with uncomplicated vaginal deliveries suggested a significantly lower rate of postpartum hemorrhage among elective cesarean deliveries but no statistical difference in the rate of blood transfusion.^69^

Hysterectomy. Three studies reported data on hysterectomy for postpartum hemorrhage.^20,^ ^38,^ ^68^ One was the Breech Trial article published in 2000 and rated of fair quality.^20^ Another study that compared planned “elective” with unplanned “emergency” was moderately relevant and of fair quality;^38^ the other was of low relevance.^68^

The Breech Trial did not report any hysterectomies.^20^ The moderately relevant study reported no significant differences in the rate of hysterectomy between elective cesarean (0.3%, 1 of 293 deliveries) and emergency cesarean (0.2%, 1 of 635 deliveries).^38^ The low relevance study reported a single case of hysterectomy for hemorrhage in the elective cesarean delivery group.^68^

Thromboembolism. Eight studies compared thromboembolism by route of delivery (Table 20). Of these studies, two were in the T relevance category (fair quality).^20,^ ^84^ Two were moderately relevant studies, one of fair quality^39^ and one of poor quality.^28^ The remaining four studies were of low relevance.^67^–^70^

Table 20 Thromboembolism

Author, Year | Measure | Outcomes for Comparison Groups | | | | | | Statistical Test Results
Relevance/Quality Rating
Hannah et al., 2000^20^ | | Planned CD | Planned VD
T/Fair | Deep vein thrombophlebitis or pulmonary embolism | 0 | 0 | | | | | NR
Leiberman et al., 1995^84^ | | Planned CD (ref grp) | Planned VD
T/Fair | Combined measure of maternal morbidity (includes febrile morbidity, endometritis, wound infection, UTI and thrombophlebitis) | 31.0% | 17.8% | | | | | P = 0.01
| OR (95% CI) | 1.0 | 0.48 (0.25; 0.89)
Burrows et al., 2004^39^ | | Primary Prelabor CD | Repeat Prelabor CD | Primary Labored CD | Repeat Labored CD | SVD (ref grp) | Operative VD
Moderate/Fair | Deep vein thrombosis | 0.2% | 0 | 0.3% | 0.1% | 0.1% | 0.04% | Signficantly different for primary labored CD
| Adj OR (95% CI) | 2.3 (0.3; 17.8) | NA | 3.9 (1.7; 8.9) | 1.9 (0.2; 14.2) | 1.0 | 0.5 (0.1; 2.2)
van Ham et al., 1997^28^ | | Primary elective CD | Primary acute CD | Secondary acute CD
Moderate/Poor | Thrombosis | 0.6% | 1.0% | 0.3% | | | | NR
| Thrombophlebitis | 1.1% | 1.8% | 3.8% | | | | NR
Golfier et al., 2001^67^ | | Elective CD | Attemped VD
Low/Not rated | Deep vein thrombosis | 0.1% | 0.7% | | | | | Outcomes not individually tested
Irion et al., 1998^68^ | | Elective CD | Attemped VD
Low/Not rated | Pulmonary embolism | 0.3% | 0 | | | | | P = 0.45
Koroukian, 2004^69^ | | Elective CD | SVD | AVD | Nonelective CD
Low/Not rated | Thrombembolic events in entire sample | 0.19% | 0.07% | 0.11% | 0.45% | | | Significantly different
| | Elective CD | Uncomplicated SVD (ref grp)
| Thrombembolic events in subset with uncomplicated deliveries | 0.19% | 0.06% | | | | | Significantly different
| RR (95% CI) | 3.45 (1.70; 7.00) | 1.0
Krebs and Lanhoff-Roos, 2003^70^ | | Elective CD | VD (ref grp) | Emergency CD (ref grp)
Low/Not rated | Thromboembolism | 0.1% | 0 | 0.1% | | | | NS
| | RR vs vaginal: 1.31 (0.95; 1.32);
| | RR vs. emergency cesarean: 0.80 (0.38; 1.26)

Adj, adjusted; AVD, assisted vaginal delivery; CD, cesarean delivery; CI, confidence interval; NA, not applicable; NR, not reported; OR, odds ratio; ref grp, reference group; RR, relative risk; SVD, spontaneous vaginal delivery; VD, vaginal delivery.

The studies universally lacked consistency in how they defined thromboembolism. Definitions varied from a composite outcome of maternal morbidity that included “thrombophlebitis” with other measures such as UTI, endometritis, and wound infection^84^ to a single thromboembolic event measure that included obstetrical air embolism, amniotic fluid embolism, obstetrical blood clot embolism, other pulmonary embolism, cerebrovascular disorders, deep phlebothrombosis, and postpartum or unspecified venous thrombosis.^69^ Two studies defined thromboembolic measures as deep venous thrombosis,^39,^ ^67^ whereas another defined it as pulmonary embolism.^68^ Yet another study assigned separate categories according to severity, defining “thrombosis” as a major morbidity outcome and “thrombophlebitis” as a minor morbidity outcome.^28^

From the Breech Trial, Hannah et al. reported no cases of either deep vein thrombophlebitis or pulmonary embolism in either the planned vaginal delivery or planned cesarean delivery group.^20^ Leiberman et al. had used the composite outcome defined above; contrary to the randomized breech trial, this group reported that this outcome was significantly higher in the planned cesarean groups than in the planned vaginal group.^84^

One moderately relevant study with a vaginal delivery group found that the risk of deep vein thrombosis was higher among both planned “without trial of labor” and “unplanned “with trial of labor” primary cesarean deliveries; the risk was significant only for the unplanned “with trial of labor” cesarean group.^39^ The other compared outcomes among planned “elective” and unplanned “acute” cesarean deliveries but did not contain a vaginal comparison group (a major limitation).^28^ Thrombosis was part of a composite outcome of postoperative complications; that measure was significantly lower in the planned cesareans than in the unplanned cesareans (no statistical testing provided).

Of the four low relevance studies, three showed neither a significant difference nor a consistent direction of effect between planned “elective” cesarean and either vaginal delivery^70^or planned vaginal delivery.^67,^ ^68^ The remaining study, from the administrative data set noted above, reported the incidence of thromboembolic events in ascending order per 1,000 deliveries: 0.7, spontaneous vaginal deliveries; 1.1, assisted vaginal deliveries; 1.9, planned “elective” cesarean deliveries; and 4.5, unplanned “non-elective” cesarean deliveries. The rate of thromboembolic events was statistically higher in unplanned cesarean than in planned cesarean deliveries.^69^

Surgical complications. The studies in this group are weighted toward surgical complications associated with cesarean deliveries. Our search parameters (reviewed by the Technical Expert Panel and the SOS Conference panel chair) were not designed to capture perineal and vaginal trauma associated with vaginal delivery. Therefore, we cannot provide a comprehensive assessment of the risks for perineal and vaginal trauma.

Of the 10 studies that compared surgical complications by mode of delivery, 1 was the Breech Trial,^20^ 3 were moderately relevant,^28,^ ^38,^ ^51^ and 6 were of low relevance^64,^ ^67^–^70,^ ^75^ (Table 21).

Table 21 Surgical complications

Author, Year | Measure | Outcomes for Comparison Groups | | | | Statistical Test Results
Relevance/ Quality Rating
Hannah et al., 2000^20^ | | Planned CD | Planned VD
T/Fair | Genital tract injury: vertical uterine incision, serious extension to transverse uterine incision, cervical laceration extending to lower uterine segment, vulvar/perineal hematoma requiring evacuation. | 0.6% | 0.6% | | | P = 1.0
| Note: There were no genital tract fistula, bowel obstructions, injury to bladder, ureter or bowel.
van Ham et al. 1997^28^ | | Primary Elective CD | Primary Acute CD | Secondary Acute CD
Moderate/Poor | Bladder lesion | 1.3% | 0.4% | 0.9% | | NS
| Lesion of the uterine artery/ligamentum latum/bowels | 0.4% | 0.6% | 0.6% | | NS
| Cervical/vaginal lesions | 0 | 0.2% | 0.6% | | NS
Bergholt et al., 2003^38^ | | Elective CD | | Emergency CD
Moderate/Fair | Cervical | 1.4% | | 4.6% | | P < 0.05
| Corporal | 0.3% | | 0.3% | | NS
| Vaginal | 0 | | 1.7% | | < 0.05
| Bladder | 0 | | 0.8% | | NS
| Bowel | 0 | | 0 | | NS
| All | 1.7% | | 6.8% | | P < 0.05
Schindl et al., 2003^51^ | | Elective CD | Intended Vaginal
Moderate/Fair | Perineal laceration III/IV | 0 | 0.2% | | | NR
| Labial, vaginal, perineal laceration I/II | 0 | 33.4% | | | NR
| Episiotomy | 0 | 20.2% | | | NR
Allen et al., 2003^64^ | | CD Without Labor | SVD (ref grp) | AVD (ref grp) | CD in Labor (ref grp)
Low/Not rated | Intraoperative trauma (Laceration of uterine artery, bladder, bowel or ureter or severe extension of uterine incision) | 0.1% | 0.1% | 0.1% | 2.6% | Only CD in labor is significantly different from CD without labor
| | RR vs SVD: 2.2 (0.3; 17.5);
| | RR vs AVD: 1.1(0.1; 9.3);
| | RR vs CD in labor: 0.1 (0.01; 0.4)
Golfier et al., 2001^67^ | | Elective CD | Planned VD
Low/Not rated | Intestinal | 0.1% | 0 | | | NR
| Wall complications (abscess/hematoma) | 2.5% | 4.1% | | | NR
| Bladder | 0 | 0.7% | | | NR
Irion et al., 1998^68^ | | Elective CD(ref grp) | Trial of Vaginal Delivery
Low/Not rated | Surgical complications (bladder or other organ injury) | 0.3% | 0.8%
| RR (95% CI) | 1.0 | 2.49 (0.26; 23.86)
Koroukian 2004^69^ | | Elective CD | SVD | AVD | Non-elective CD
Low/Not rated | Obstetrical Trauma: Laceration of cervix, high vagical laceration, other injury to pelvic organs, damage to pelvic joints and ligaments, other specified obstetrical trauma, unspecified obstetrical trauma in entire sample | 1.09% | 7.35% | 7.05% | 0.57%
| | Elective CD(ref grp) | Uncomplicated SVD
| Obstetrical Trauma: Laceration of cervix, high vaginal laceration, other injury to pelvic organs, damage to pelvic joints and ligaments, other specified obstetrical trauma, unspecified obstetrical trauma in subset of uncomplicated deliveries | 1.09% | 6.94% | | | Significantly different
| RR (95% CI) | 1.0 | 0.16 (0.16; 0.20)
| | Elective CD | SVD | AVD | Non-elective CD
| Obstetrical surgical wound complications: includes hematoma, hemorrhage, or infection of cesarean or perineal wound in entire sample | 3.0% | 0.25% | 0.49% | 3.61%
| | Elective CD(ref grp) | Uncomplicated SVD
| Obstetrical surgical wound complications: includes hematoma, hemorrhage, or infection of cesarean or perineal wound in subset of uncomplicated deliveries | 3.0% | 0.25% | | | Significantly different
| RR (95% CI) | 1.0 | 12.5 (10.00; 15.63)
Krebs and Langhoff-Roos, 2003^70^ | | Elective CD | VD | Emergency CD (ref grp)
Low/Not rated | Bladder injury | 0.1%, | 0 | 0.2%
| RR (95% CI) | 0.58 (0.23; 1.02) | NA | 1.0
Phipps et al., 2005^75^ | | Scheduled CD | Urgent CD | Emergent CD
Low/Not rated | Bladder injury | In this case control study, women with a bladder injury were statistically more likely to have undergone an emergent or urgent cesarean than an elective cesarean

AVD, assisted vaginal delivery; CD, cesarean delivery; CI, confidence interval; NS, not significant; ref grp, reference group; RR, relative risk; SVD, spontaneous vaginal delivery; VD, vaginal delivery.

Similar to the practices seen for other maternal outcomes, we found some studies that defined surgical complications as a single composite measure of injury,^64,^ ^68,^ ^69^ and others that reported specific measures of complications such as bladder or bowel injury.^20,^ ^28,^ ^38,^ ^51,^ ^67,^ ^70,^ ^75^

The Breech Trial (fair quality) found similar rates of genital tract injury (vertical uterine incision, serious extension to transverse uterine incision, cervical laceration extending to lower uterine segment, or vulvar/perineal hematoma requiring evacuation) among the planned vaginal group (0.6%) and the planned cesarean group (0.6%).^20^ Neither group experienced genital tract fistulae, bowel obstructions, or injury to bladder, ureter, or bowel.

Two of the three moderately relevant studies were of fair quality^38,^ ^51^ and one was of poor quality.^28^ These three studies varied widely in their choice of comparison groups. The only moderately relevant study that compared planned “elective” cesarean with planned vaginal delivery “intended vaginal birth” focused primarily on perineal surgical injury.^51^ In this study, 33.4 percent of women in the planned vaginal delivery group experienced labial, vaginal, or first or second degree perineal lacerations; another 20.2 percent had an episiotomy; and 0.2 percent experienced a third or fourth degree laceration; as expected, no such complications occurred in the elective cesarean group. No abdominal surgical complications were reported for either the planned cesarean or the planned vaginal delivery group.

The two remaining moderately relevant studies were limited to comparisons of outcomes among cesarean deliveries.^28,^ ^38^ One suggested a higher rate of surgical complications among women with unplanned (“emergency” or “labored”) cesarean delivery than among women with planned “elective” or “unlabored” cesarean;^38^ the other did not.^28^

Three of the six studies of low relevance to CDMR compared surgical complications between planned “elective” cesarean and planned vaginal delivery.^64,^ ^67,^ ^68^ All three reported slightly higher rates of surgical complications in the planned vaginal delivery group although these were not statistically significant.

Three other low relevance studies compared groups based on actual routes of delivery.^69,^ ^70,^ ^75^ One study using composite outcomes reported a higher rate of obstetrical (pelvic) trauma in spontaneous vaginal delivery (7.35 percent) and assisted vaginal delivery (7.05 percent) than in planned “elective” cesarean (1.09 percent) or unplanned “non-elective” cesarean delivery (0.57 percent). A subanalysis comparing planned cesarean to uncomplicated spontaneous vaginal delivery yielded similar findings. Two studies found that the rate of bladder injury was lower in planned “elective” cesarean than in unplanned “emergency”^70^or “emergent” or “urgent” cesarean deliveries.^75^

Breastfeeding. Two articles (rated poor) from the Breech Trial^18,^ ^83^ provided evidence on initiation and duration of breastfeeding for women experiencing planned vaginal or planned cesarean delivery. The percentages of women initiating breastfeeding “within a few hours” were 77.6 percent for planned vaginal and 73.3 percent for planned cesarean; the difference bordered on statistical significance (P = 0.05).^18^ The percentages of women breastfeeding at 3 months and at 2 years were nearly identical.^18,^ ^83^

Postpartum pain. Four articles comprising three studies addressed postpartum pain.^18,^ ^43,^ ^51,^ ^83^ Two articles reported later analyses for the Breech Trial (“T,” both rated poor).^18,^ ^83^ The other two were moderately relevant, one of fair quality^51^ and one of poor quality.^43^

The Breech Trial examined numerous pain outcomes at 3 months postpartum: any pain, location of pain, severity of pain, and use of analgesics during the past 24 hours and found no difference in the incidence of pain, severity of pain, or use of analgesics.^18^ As expected, at 3 months postpartum women in the planned vaginal delivery group were significantly more likely to report pain in the “bottom or genital area,” and women in the planned cesarean delivery group were more likely to report pain on the “outside of the abdomen” or “deep inside the abdomen.”^18^ These difference were no longer significant at 2 years postpartum.^83^

Of the two moderately relevant studies, the fair quality study reported maternal pain using a visual analog scale (VAS) ranging from 1 (no pain) to 10 (most severe pain),^51^ that they administered at 3 days and at 4 months postpartum. At the 3-day postpartum evaluation, patients were also asked to rate retrospectively their pain at delivery. The authors presented results only in graphs, with no numerical outcomes for the VAS. They depicted a significantly higher median pain level during birth for the vaginal or assisted vaginal delivery groups than for the cesarean group. However, the authors commented that “peridural” anesthesia was offered to every woman but that only 11 percent chose it.^51^ At 4 months postpartum, they observed no significant difference in “momentary birth-related pain” among the groups. The investigators presented data for a group of women who underwent “cesarean on demand” for reasons including anxiety in nulliparous women, previous traumatic birth, coordination problems, and safety considerations. However, they did not report their data in a way that permitted us to abstract usable information, comment on laboring status in this group, or note specific analyses on this subset of patients.

The other moderate relevant (poor quality) study used a one-item Pain Intensity Scale within one week of delivery.^43^ This study found no difference in mean pain intensity scores among unplanned cesareans, planned cesareans, and vaginal delivery.

Psychological outcomes: postpartum depression. Four articles comprising two studies dealt with postpartum depression associated with mode of delivery. The Breech Trial (rated “T”) contributed one article of fair quality^20^ and two of poor quality;^18,^ ^83^ the fourth study was of low relevance to CDMR.^66^

The Breech Trial report (rated poor) defined depression as a score of more than 12 on the validated Edinburgh Postnatal Depression Scale.^18^ The low relevance study used the validated Center for Epidemiologic Studies Depression Scale. Neither study reported significant differences at any time point.^18,^ ^20,^ ^83^

Psychological outcomes: other. Seven articles representing six studies reported on a variety of psychological outcomes other than depression; these studies used outcomes, measures, instruments, and time points for outcome measurement that have little in common. The two articles from the Breech Trial are rated “T” and are of poor quality,^18,^ ^83^ two are moderately relevant,^43,^ ^51^ and three are of low relevance.^66,^ ^76,^ ^78^ In general terms, women who experienced an unplanned cesarean birth or an instrumental vaginal delivery were more likely to experience adverse psychological outcomes than were women who underwent either a spontaneous vaginal or a planned cesarean birth.

The Breech Trial article reporting 3-month outcomes (rated poor) found that women in the planned cesarean delivery group were more likely than those in the planned vaginal birth group to indicate that they “liked being able to schedule their delivery” and “liked that childbirth experience was not very painful.”^18^ Women in the planned vaginal birth group were more likely than those in the planned cesarean group to indicate that they liked that the delivery was natural, liked actively participating in the birth, and liked that recovering from the childbirth experience was not difficult. These authors reported no differences between planned vaginal and planned cesarean births in women feeling reassured about their own health. In general, despite the differences in likes and dislikes, the planned vaginal and planned cesarean did not differ as to whether women would “participate in the trial if they had to do it all over again” (p. 1828).^18^ The follow-up study reporting outcomes at 2 years (rated poor) found no difference in the experience of being a mother, the relationship with husband or partner, or the relationship with husband or partner compared with that before the child was born.^83^

Of the two moderately relevant studies, one fair-rated study^51^ used the Zerrsen test^93^ for quantifying momentary personal feelings and a modified version of a birth experience questionnaire by Salmon and Drew.^94^

These investigators reported no differences in momentary personal feelings before birth. At 3 days postpartum, women in the assisted vaginal delivery and emergency cesarean delivery groups reported strong negative feelings. These differences dissipated by 4 months postpartum. In contrast, women planning a cesarean delivery without medical indications had an expectation of a more pleasant birth than did women planning a vaginal delivery or a cesarean for medical indications. Of the 44 cesareans performed “on demand,” 20 (45 percent) were for women who had had a previous traumatic birth. At 3 days postpartum, the most positive birth experiences were reported by the group with planned cesarean without medical indications, followed in descending order by those with cesarean for medical indications, vaginal delivery, emergency cesarean, and assisted vaginal delivery. Results were similar at 4 months postpartum. The other moderately relevant (poor) study, using the Perception of Birth Scale^95^ found no differences between the vaginal and planned cesarean delivery groups or the planned and unplanned cesarean groups.^43^ However, women in the unplanned cesarean group had a more negative perception of the birth experience than did women in the vaginal group.

One low relevance study compared adaptive and ineffective responses during three time periods (1973-1980, 1981-1982, and 1989-1990). In the first and the last time periods, women in the unplanned cesarean group had a significantly lower percentage of adaptive responses and a higher percentage of ineffective responses than women who had a planned cesarean delivery. This finding was not statistically significant in the second time period.^76^ A second study of low relevance appraised birth experience, neuroticism, and self-esteem.^66^ None of these outcomes differed at 4 or 12 months among planned cesarean, unplanned cesarean, and vaginal delivery groups. A third study of low relevance to CDMR reported that women in the emergency cesarean and the assisted vaginal delivery groups had the most negative cognitions and emotions regarding the delivery overall compared with elective cesarean and normal vaginal delivery.^78^

Maternal length of stay. Four studies reported on length of stay; one was the Breech Trial (fair quality)^20^ and three were of moderate relevance (poor quality)^28,^ ^43,^ ^50^ (Table 22). The studies varied in comparison groups. Two investigated outcomes by intended route of delivery: planned vaginal vs. planned cesarean delivery,^20,^ ^50^ and both reported a significantly higher median length of stay in the planned cesarean group. A third study reported length of stay separately for “planned” and “unplanned” cesarean deliveries and found significantly higher length of hospital stay among “unplanned” and “planned” cesarean compared with vaginal deliveries.^43^ The fourth study limited outcomes to cesarean deliveries and found that the length of stay following a planned “elective” cesarean was shorter than among unplanned “acute” deliveries.^28^ However, the authors provided no statistical test results. The results were consistent in demonstrating a longer hospital stay following planned or unplanned cesarean than following vaginal delivery.

Table 22 Maternal length of stay

Author, Year | Measure | Outcomes for Comparison Groups | | | Statistical Test Results
Relevance/Quality Rating
Hannah et al., 2000^20^ | | Planned CD | Planned VD
T/Fair | Median length of hospital stay in days | 4 | 2.8 | | P<0.0001
Fawcett et al., | | Planned CD | Unplanned CD | VD
Moderate/Poor | Mean length of hospital stay in days (range) | 4.9 (3–12) | 4.8 (3–10) | 2.5 (1–14) | P<0.05
Sanchez-Ramos et al., 2001^50^ | | Elective CD | Attempted VD
Moderate/Poor | Mean length length of hospital stay in days (range) | 4 (4,4) | 2 (2,3) | | P=0.0001
van Ham et al., 1997^28^ | | Primary Elective CD | Primary acute CD | Secondary Acute CD
Moderate/Poor | Mean length of stay (SD) | 7.2 (2.4) | 7.8 (3.1) | 7.6 (1.9) | NS, details NR

CD, cesarean delivery; CI, confidence interval; NR, not reported; NS, not significant; SD, standard deviation; VD, vaginaldelivery.

Urinary incontinence. Nine articles comprising eight studies reported on urinary incontinence associated with mode of delivery (Table 23). Two articles were from the Breech Trial.^18,^ ^83^ Two were moderately relevant,^41,^ ^44^ and five were of low relevance.^70,^ ^73,^ ^74,^ ^79,^ ^82^

Table 23 Urinary incontinence

Author, Year | Measure | Outcomes for Comparison Groups | | | | | Controls for Previous Incontinence | Time Period | Statistical Test Results
Relevance/Quality Rating
Hannah et al., 2002^18^ | | Planned CD | Planned VD
T/ Poor | SUI | 4.50% | 7.30% | | | | No | 3 mos PP | P = 0.02
| OR (95% CI) | 0.62
| | (0.41; 0.93)
Hannah et al.,2004^83^ | | Planned CD | Planned VD
T/Poor | SUI | 17.80% | 21.80% | | | | No | 2 yrs PP | P = 0.14
| OR (95% CI) | 0.81 (0.63; 1.06)
Farrell et al., 2001^41^ | | Elective CD | SVD | Forceps | All CD (ref grp) | CD in 2nd Stage of Labor
Moderate/Fair | SUI | 4.00% | 23.00% | 35.00% | 8.00% | 5.00% | Yes | 6 wks PP | SVD and forceps significantly different from all CD
| RR (95% CI) | | 2.8 (1.5; 5.3) | 4.3 (2.2; 8.2)
| | 5.00% | 22.00% | 33.00% | 10.00% | 3.00% | Yes | 6 mos PP | SVD and forceps significantly different from all CD
| RR (95% CI) | | 2.1 (1.1; 3.7) | 3.1 (1.7; 5.9)
Groutz et al., 2004^44^ | | Elective CD | SVD (ref grp) | CD for Obstructed Labor
Moderate/Fair | SUI | 3.40% | 10.30% | 12% | | | Yes | 1 yr PP | Elective CD significantly different compared to SVD
| | P = 0.02 | | P = 0.7
Krebs et al., 2003^70^ | | Elective CD | VD | Emergency CD
Low/Not rated | Hospitalization for either urinary incontinence or vaginal descensus | 0.60% | 0.60% | 0.5% as reported in article, 1.4% as calculated by authors of this report | | | No | NR | NS
Mason et al., 1999^73^ | | Planned CD | VD | Emergency CD | Forceps | Ventouse
Low/Not rated | SUI | 15.90% | 34.90% | 17.10% | 32.10% | 40.10% | No | NR | X^2^=10.85P=0.0009 for VD vs elective CD and emergency CD, other comparisons NS
Persson et al., 2000^74^ | Surgery for urinary incontinence | | | | | | | | Groups and rates NR, but OR for elective cesarean vs. non-instrumental vaginal singleton births among primiparous women: 0.21 (95% 0.13–0.34); OR for any cesarean vs. non-instrumental VD: 0.34 (95% CI 0.23–0.52)
Low/Not rated
Schytt et al., 2004^79^ | | Elective CD | SVD (ref grp) | Instrumen-tal VD | Emer-gency CD
Low/Not rated | SUI for primiparous women | 0 | 19.9% | 21.8% | 11.5% | | No | 1 yr PP | Multivariate analysis combined elective and emergency CD and found a protective effect compared with SVD (OR: 0.4 95% CI 0.2–0.9); instrumental VD not significantly different from SVD
| OR (95% CI) | NA | 1.0 | 1.1 (0.8; 1.6) | 0.6 (0.3; 1.0)
| SUI for multiparous women | 12.9% | 25.4% | 38.5% | 12.7% | | No | 1 yr PP | Neither CD (emergency and elective combined) nor instrumental VD is significantly different from SVD
| OR (95% CI) | 0.5 (0.3; 0.9) | 1.0 | 1.5 (1.0; 2.3) | 0.5 (0.3; 1.0)
Wilson et al., 1996^82^ | | Elective CD | SVD (ref grp) | Forceps | CD in 1st Stage of Labor | CD in 2nd Stage of Labor
Low/ Not rated | SUI among all women with no previous incontinence | 8.90% | 24.40% | 27.00% | 12.00% | 7.70% | Yes | 3 mos PP | Elective CD significantly different compared to SVD
| OR (95% CI) | 0.3 (0.1; 0.6) | | 1.3 (0.8; 2.3) | NR | NR
| | Elective CD | SVD (ref grp) | Forceps | CD in 1st Stage of Labor | CD in 2nd Stage of Labor
| SUI in primaparous subset | 0.00% | 24.50% | 25.20% | 6.10% | 8.30% | NR | 3 mos PP | Elective CD significantly different compared to SVD
| OR (95% CI) | 0.2 (0.0; 0.6) | | 1.0 (0.5; 1.9) | NR | NR

CD, cesarean delivery; CI, confidence interval, NR, not reported: NS, not signficant; OR, odds ratio; PP, postpartum; ref grp, reference group; RR, relative risk; SVD, spontaneousvaginal delivery; VD, vaginal delivery.

The Breech Trial was designed primarily to focus on neonatal outcomes following planned vaginal vs. planned cesarean for breech. As such, it has significant limitations to outcomes related to pelvic floor disorders since the study included multiparous women, allowed randomization in labor, suffered from a high degree of crossover, was performed in 26 countries, used nonvalidated instruments in multiple languages, and more than 50 percent of participants required assistance in completing the questionnaires. The 2002 Breech Trial article (poor quality) suggested that planned cesarean delivery significantly reduced the risk of urinary incontinence compared with planned vaginal delivery at 3 months, with a relative risk of 0.62 (95% CI, 0.41–0.93).^18^ In the 2-year postpartum article (poor quality), the rates of urinary incontinence remained higher in the planned vaginal group than in the planned cesarean group, but the difference was no longer statistically significant.^83^ The rates of urinary incontinence were about three times as high at 2 years in both groups as at 3 months postpartum. The authors suggested that a change in the reference period in the outcome measurement may explain this difference. At 3 months, women were asked about urinary incontinence in the past 7 days; by contrast, at 2 years, women were queried about the past 3 to 6 months.^83^

The two moderately relevant studies (both fair) were prospective cohort studies; they investigated symptoms of stress urinary incontinence according to actual mode of delivery and adjusted for preexisting urinary incontinence. One study found that planned “elective” cesareans performed before labor and cesareans performed during the first stage of labor appeared to be significantly protective against urinary incontinence compared with spontaneous vaginal deliveries.^41^ Overall, the risk of postpartum urinary incontinence at 6 weeks was as follows: forceps, 35 percent; spontaneous vaginal delivery, 23 percent; cesarean in labor, 9 percent; and elective cesarean, 4 percent. In the other moderately relevant study, the prevalence of stress urinary incontinence 1 year postpartum was not significantly different among primiparous women who underwent a spontaneous vaginal delivery (10.3 percent) from the rate among women who had a cesarean delivery for obstructed labor (12.0 percent), but was significantly lower for women who underwent an elective cesarean (3.4 percent) (P = 0.02).^44^

Three of the five low relevance studies compared symptoms of stress urinary incontinence by actual route of delivery. Two concluded that cesarean delivery had a protective effect relative to vaginal delivery.^73,^ ^82^ The third showed lower rates of stress urinary incontinence for women who had a cesarean delivery compared with women who had a vaginal delivery; these results were statistically significant for primiparous women only.^79^

The remaining two studies of low relevance to CDMR linked surgical administrative databases and birth registries to assess the association between route of delivery and surgery for stress urinary incontinence^74^or hospitalization for either stress incontinence or “vaginal descensus.”^70^ They yielded conflicting information about urinary incontinence issues.

Anorectal function. Of the seven articles comprising six studies (Table 24) that reported on anal incontinence associated with mode of delivery, two were from the Breech Trial.^18,^ ^83^ Two others were moderately relevant,^42,^ ^46^ and three were of low relevance.^70^–^72^

Table 24 Anorectal function

Author, Year | Measure | Outcomes for Comparison Groups | | | | | | Controls for Previous Incontinence | Time Period | Statistical Test Results
Relevance/Quality Rating
Hannah et al., 2002^18^ | | Planned CD | Planned VD
T/Poor | Fecal incontinence | 0.8% | 1.5% | | | | | No | 3 mos PP | P = 0.29
| RR (95% CI) | 0.54 (0.18–1.62) | 1.0
Hannah et al., 2004^83^ | | Planned CD | Planned VD
T/Poor | Fecal incontinence | 2.4% | 2.2% | | | | | No | 2 yrs PP | P = 0.83
| RR (95% CI) | 1.10 (0.47–2.58) | 1.0
Farrell et al., 2001^42^ | | Elective CD | SVD | Forceps | All CD (ref grp) | CD in 2nd Stage of Labor
Moderate/Fair | Flatal incontinence | 31% | 16% | 34% | 19%* | 17% | | Yes | 6 wks PP
| RR (95% CI) | | 0.8 (0.5; 1.5) | 1.8 (1.0; 3.1)
| Flatal incontinence | 0% | 17% | 44% | 18% | 21% | | Yes | 6 mos PP PP
| RR (95% CI) | | 1.0 (0.6; 1.8) | 2.5 (1.4; 4.5)
| Fecal incontinence | 4% | 4% | 9% | 2% | 2% | | Yes | 6 mos PP PP
| RR (95% CI) | | 1.7 (0.5; 5.9) | 3.6 (1.0; 13.4)
Lal et al., 2003^46^ | | Elective CD | Emergency CD | VD (Non-instrumental)
Moderate/Fair | New anal incontinence | 3.8% | 5.8% | 8% | | | | Yes | 10+/-2 mos PP | NR
| Severe fecal incontinence | 2.5% | 0 | 1% | | | | Yes | 10+/-2 mos PP | P = 0.716
Krebs and Langhoff-Roos, 2003^70^ | | Elective CD | VD | Emergency CD
Low/Not rated | Anal sphincter rupture | 0 | 1.7% | 0 | | | | No | Up to 23 years PP | NS
MacArthur et al., 2001^72^ | | Elective CD | SVD (ref grp) | Forceps | Vaccum | Breech | Emer-gency CD
Low/Not rated | Fecal incontinence in all women | 7.3% | 9.6% | 13.6% | 10.3% | 13.8% | 7.5% | No | 3 mos PP | NR
| Fecal incontinence in primiparous subset | 5.4% | 8.8% | 13.9% | 9.3% | 12.0% | 4.8% | No | 3 mos PP | NR
| | Multiple regression of primiparous women combined emergency and elective cesareans and showed that cesareans overall had a lower risk of fecal incontinence than did spontaneous vaginal deliveries (OR = 0.58; 95% CI, 0.35–0.97) | | | | | | No | 3 mos PP | Significantly different
| Fecal incontinence in multiparous subset | 8.0% | 10.0% | 12.2% | 14.3% | 15.0% | 12.3% | No | 3 mos PP | NR
MacArthur et al., 1997^71^ | | Elective CD | SVD (ref grp) | Forceps | Vaccum | Emergency CD
Low/Not rated | Fecal incontinence in all women | 0 | 3.2% | 7.2% | 22.2% | 5.3% | | Yes | 45 weeks PP | Only forceps and vaccum are significantly different from SVD
| | NS significant “because of small numbers,” | | P = 0.027 | P = 0.002 | NR | | Yes
| Fecal incontinence in primiparous subset | 0 | 2.6% | 5.8% | 21.4% | 8.5% | | Yes
| Fecal incontinence in multiparous subset | 0 | 3.4% | 12.5% | 25.0% | 1.9% | | Yes

CD, cesarean delivery; CI, confidence interval; NR, not reported; NS, not signficant; PP, postpartum; SVD, spontaneous vaginal delivery; VD, vaginal delivery.

* :Note this figure is reported as both 19% and 31% in a single table in the article; the figure of 31% appears to be a typographical error.

Six articles assessed symptoms of anal incontinence.^18,^ ^42,^ ^46,^ ^71,^ ^72,^ ^83^ The seventh, a population-based study, linked an administrative database and birth registry of primiparous women who delivered singleton breech infants at term to assess the association between route of delivery and anal sphincter rupture over a period of up to 23 years.^70^

Of the six studies reporting on symptoms, all but one included flatal incontinence in addition to involuntary loss of solid or liquid stool in their definition of anal incontinence. The remaining study limited its definition of anal incontinence to frank incontinence and fecal urgency.^71^

Three studies assessed women for preexisting anal incontinence.^42,^ ^46,^ ^71^ No study used a validated instrument. The time period for the assessment of anal incontinence ranged from 3 months^18^ to 2 years.^83^

The two Breech Trial reports (rated poor)^18,^ ^83^ used different measures at two time points; questions related to fecal incontinence were added after some participants had already completed the study. At 3 months, the authors queried participants regarding whether they had experienced fecal incontinence in the past 7 days.^18^ At 2 years, however, the participants were asked about fecal incontinence over the previous 3 to 6 months.^83^ Neither article reported a significant difference in rates of fecal incontinence between planned vaginal and planned cesarean.

The two moderately relevant studies were of fair quality.^42,^ ^46^ One reported new onset symptoms of anal incontinence in 3 of 80 women (3.8 percent) in the planned “elective” cesarean group, 6 of 104 women (5.8 percent) in the unplanned “emergency” cesarean group, and 8 of 100 (8 percent) in the vaginal delivery group.^46^ This progression suggested an increasing risk of fecal incontinence with emergency cesarean and vaginal delivery compared with elective cesarean. However, the authors limited their statistical comparison to overall cesarean (elective and emergency) against vaginal delivery (P = 0.427). They also noted a higher risk of severe fecal incontinence after elective cesarean, 2 of 80 women (2.5 percent), than after emergency cesarean, 1 of 104 women (0.96 percent); the latter rate was similar to that for vaginal delivery, 1 of 100 women (1 percent). The authors suggested that elective cesarean is not always protective and that symptoms of fecal incontinence associated with elective delivery can be severe. However, these results need to be interpreted with caution given the low incidence rates overall.

The other moderately relevant study reported a significantly lower rate of flatal incontinence at 6 months in the planned “elective” cesarean group (0 percent) than in the unplanned “in labor” cesareans (21 percent).^42^ The authors of the study noted that the risk of flatal incontinence was higher with forceps-assisted delivery than with spontaneous vaginal delivery and that the risk of both flatal and fecal incontinence was higher in both groups than in all cesarean deliveries.

Of the three low relevance studies, one reported that primiparous women had no cases of anal incontinence in the elective cesarean group (0 of 13 women).^71^ For the other modes of delivery, the rates of anal incontinence in descending order were as follows: vacuum delivery, 3 of 14 women (21.4 percent); emergency cesarean, 5 of 59 women (8.5 percent); forceps delivery, 5 of 86 women (5.8 percent); and spontaneous vaginal delivery, 5 of 189 women (2.6 percent). Similarly, among multiparous women, no case of anal incontinence occurred in the elective cesarean group (0 of 48 women). The overall rates of fecal incontinence in descending order were as follows: vacuum delivery, 1 of 4 women (25.0 percent); forceps delivery, 3 of 24 women (12.5 percent); spontaneous vaginal delivery, 13 of 379 women (3.4 percent); and emergency cesarean, 1 of 54 women (1.9 percent). The authors reported no statistically significant difference among groups and attribute this to small numbers. The authors performed logistical regression modeling and found that both vacuum and forceps were statistically associated with anal incontinence, P = 0.002 and P = 0.027, respectively.

Another low relevance study was a prospective questionnaire study comparing symptoms and actual route of delivery.^72^ Cesareans overall had a lower risk of fecal incontinence than did spontaneous vaginal deliveries (OR = 0.58; 95% CI, 0.35–0.97). This study also found a higher risk of fecal incontinence associated with forceps deliveries than with spontaneous vaginal delivery (OR = 1.94; 95% CI, 1.30–2.89).

The other low relevance study from the administrative database reported no case of anal sphincter rupture in either the elective (n = 7,503) or emergency cesarean groups (n = 5,575).^70^ They did report, however, 41 of 2,363 cases (1.7 percent) in the vaginal delivery group. No group had any hospitalizations for either anal incontinence or fistula.

Pelvic organ prolapse. One low relevance study that examined pelvic organ prolapse associated with various actual modes of delivery, using an administrative data set compared hospitalizations for either vaginal descensus or urinary incontinence between 5 and 18 years after delivery.^70^ The publication appears to have a typographical error. The rate of hospitalization for either prolapse or urinary incontinence was reported as 42 of 7,503 (0.6%) for elective cesarean, 13 of 2,363 (0.55%) for vaginal delivery, and 80 of 5,575 (1.4%) for emergency cesareans. However, the actual manuscript reports the rate of hospitalization in the emergency cesarean group as “80/5575 (0.5%).” The authors report that difference in hospitalization for either pelvic organ prolapse or urinary incontinence did not differ statistically, but they state that they are unsure how to interpret these results accurately. The potential error seems limited to the emergency cesarean group.

Sexual function. Two articles comprising the Breech Trial,^18,^ ^83^ received a relevance rating of T, were of poor quality, and included sexual function outcomes. Sexual function was measured differently at three months and two years after delivery. At three months, measures included sex since birth and pain during sex on most recent occasion. At two years, measures included aparuenia, dysparuenia, the presence and extent of sexual problems and happiness with sexual relations. No statistically significant differences were noted at either time point for any measure. However, we note that none of the measures was validated and the instruments were administered in multiple languages and with the assistance of translators.

### Maternal Outcomes Relevant to Subsequent Cesarean Deliveries

As noted in Chapter 2, our search strategy focused on outcomes of primary cesarean deliveries. However, we recognize that any decision related to CDMR needs to balance the comprehensive risks and benefits for both mother and infant, for short- and long-term complications associated with first and future cesarean deliveries. The following outcomes, as such, are particularly relevant to subsequent cesarean deliveries. We augment the following discussion by summarizing or updating other systematic reviews on the following topics.

Subsequent fertility issues. We identified a single study that examined subsequent fertility issues including admissions for infertility, ectopic pregnancy, and hospitalization for miscarriage. It study reports similar rates among elective cesarean, emergency cesarean, and vaginal delivery.^70^ The study controls for mode of delivery in the first pregnancy but not subsequent pregnancies and therefore does not contribute usable data to answer the question.

Subsequent uterine rupture. We identified a single study reporting a higher rate of uterine rupture in emergency cesarean delivery (3/636, 0.5%) compared to “elective” cesarean delivery (0/294).^38^ This study did not include a vaginal delivery comparison group, thus limiting its utility. Nonetheless, this issue is of interest to the SOS conference, and we attempted to address it through a summary of results of the recent update^32^ of the AHRQ systematic review on vaginal birth after cesarean.^96^ The update noted that several large cohort studies of fair or poor quality investigated the incidence of uterine rupture of a cesarean scar and factors that affect the risk, but classification and terminology were inconsistent across the studies. Reports used two definitions: “asymptomatic uterine rupture of a cesarean scar” to indicate the opening of a prior incision with no signs or symptoms, also called uterine dehiscence; and “symptomatic uterine rupture of a cesarean scar” to indicate uterine separation diagnosed at laparotomy performed because of fetal heart rate disturbances, maternal bleeding, or other signs of maternal or neonatal consequences. The update found no statistically significant differences between trial of labor after cesarean and elective repeat cesarean delivery with regard to asymptomatic uterine rupture rates. It also reported two studies of fair or good quality^97^ that yielded a higher (but small) risk of symptomatic uterine rupture in women receiving a trial of labor after previous cesarean than among women receiving elective repeat cesarean delivery, with “an increased risk of 2.7/1,000 deliveries”^96^ (page 3).

Placenta previa. Summary of recent meta-analysis. One frequently cited repercussion of cesarean delivery is abnormal placentation, in particular, placenta previa in subsequent deliveries. For this outcome, we summarized and then updated a recent review by Faiz and Ananth.^31^ This meta-analysis examined etiology and risk factors for placenta previa by reviewing 58 observational studies published between 1966 and 2000. These 58 studies included 32 hospital-based retrospective cohort studies, 15 hospital-based case-control studies, 6 population-based case-control studies, and 5 population-based retrospective cohort studies. Study populations ranged from 6,576 to 1,825,998 pregnancies. Placenta previa prevalence estimates were between 1.0 and 19.7 per 1,000 births. Faiz and Ananth derived placenta previa rates of 3.5 to 4.6 per 1,000 pregnancies based on study type and geographic location.

In all, 21 studies evaluated by Faiz and Ananth investigated the association between placenta previa and previous cesarean delivery; of these, they considered 4 to be well-designed studies. They calculated random-effects pooled odds ratios that ranged from 1.9 (95% CI, 1.7–2.2) for well-designed studies to 3.5 (95% CI, 2.7–4.6) for poorly designed studies.

Advancing maternal age and increasing parity were also associated with increased odds of placenta previa, with the highest risk found in women of both advanced age and advanced parity. As an example provided in the meta-analysis, for a woman age 40 or older, with three previous pregnancies, the odds ratio of placenta previa in this meta-analysis was 11.96 (95% CI, 10.80–13.24); by contrast, for a woman 20 to 24 years of age and of parity one, the odds ratio was 1.61 (95% CI, 1.50–1.72). These associations could prove important confounders in any association between previous cesarean delivery and placenta previa.

Our update of recent meta-analysis. Applying the same search methods that Faiz and Ananth used for their meta-analysis,^31^ we examined the literature on placenta previa published between 2000 and 2005. We identified 131 articles, reviewed 34 full-text articles, and included all 13 articles that met inclusion criteria (namely, published between March 2000 and May 2005, English language, observational study of placenta previa diagnosed in third trimester or at delivery, with evaluation of cesarean delivery as a risk factor for placenta previa). We excluded case reports and studies without a comparison group. We included five hospital-based case-control studies, four hospital-based retrospective cohort studies, two population-based retrospective cohort studies, and one hospital-based and one clinic-based cross-sectional study. As in the recent meta-analysis, our summary table (Table 25) is presented by study design. Our populations ranged from 272 to 370,374 and up to 740,748 deliveries; prevalence estimates for placenta previa ranged from 1.9 to 5.2 per 1,000 pregnancies. Using Faiz and Ananth's quality scoring system for study design (1–5) and method of diagnosis of placenta previa (1–4), we assigned two quality scores to each study: 5 and 4 represented the best quality, respectively. We gave seven studies quality scores of 4 and six studies quality scores of 3 for diagnostic technique, taking into account how well the technique was specified. For quality of study design, six studies received scores of 4 or 5, five studies received scores of 3, and two studies scores of 2 (Table 26).

Table 25 Description of studies addressing placenta previa relative to a history of previous cesarean delivery

Author | Study Design | Data Source | Study Population Size | Effect Measure
Study Location | | | | Crude (COR) or Adjusted (AOR) Odds Ratio (95% C.I.) or Prevalence
Study dates
Crane et al., 2000^99^ | Retrospective cohort, population-based | Nova Scotia Atlee Perinatal Database, all deliveries in Nova Scotia | 308 PPs | [underlined: OR for hysterectomy during CD for PP, relative to prior CD:]
Canada | | | 93,996 deliveries | COR 11.90(3.70,38.26)
1988-1995 | | | | AOR 16.92(3.51,81.70)
| | | | (Adjusted for placenta accreta, maternal age, gestational age, antepartum bleed)
Lydon-Rochelle et al., 2001^100^ | Retrospective cohort, population-based | Washington State Birth Events Record Database from hospital discharge data | 493 PPs | [underlined: OR for PP at second birth, relative to prior CD vs. VD at first birth:]
USA | | | 95,630 subjects | AOR 1.4(1.1,1.6)
1987-1996 | | | | (Adjusted for age)
Francois et al., 2001^101^ | Retrospective cohort, hospital-based | Good Samaritan Regional Medical Center, ICD-9 codes | 55 PPs | [underlined: Percentage of PP deliveries with history of prior CD:] 5/55 = 9.1%
USA | | | 29,268 deliveries
1997-2000
Dashe et al., 2002^98^ | Retrospective cohort, hospital-based | Ultrasound and obstetric database at Parkland Hospital | 230 PPs persisted | [underlined: OR for persistent PP relative to prior CD, for diagnosis made at each gestational age category:]
USA | | | 714 PPs diagnosed | [underlined: 15–19 wks:]
1991-2000 | | | | COR 2.6(1.2,5.4)
| | | | AOR 2.3(1.1,4.9)
| | | | [underlined: 20–23 wks:]
| | | | COR 4.7(1.8,12.2)
| | | | AOR 4.9(1.7,14.0)
| | | | [underlined: 24–27 wks:]
| | | | COR 5.3(1.8,15.4)
| | | | AOR 4.5(1.3,14.9)
| | | | [underlined: 28–31 wks:]
| | | | COR 1.2(0.6,2.7)
| | | | AOR 1.1(0.4,2.6)
| | | | [underlined: 32–35 wks:]
| | | | COR 1.5(0.6,3.6)
| | | | AOR 1.8(0.7,4.9)
| | | | (Adjusted for age, parity, type of PP)
Rasmussen et al., 2000^102^ | Retrospective cohort, hospital- based | Medical Birth Registry of Norway and population census | 826 PPs | [underlined: OR for PP in second pregnancy relative to prior CD in first pregnancy:]
Norway | | | 370,374 subjects | COR: 1.61(1.28–2.03)
1967-1992 | | | 740,748 deliveries | AOR: 1.32(1.04–1.68)
| | | | (Adjusted for age, prior placental previa)
Sheiner et al., 2001^101^ | Retrospective cohort, hospital- based | Soroka University Medical Center medical records | 298 PPs | [underlined: Prevalence of prior CD:]
Israel | | | 78,524 pregnancies | In patients with previa: 20.5%
1990-1998 | | | | In patients without previa: 9.8% (P < 0.001)
| | | | [underlined: OR for PP, relative to prior CD:]
| | | | AOR 1.8 (1.4–2.4)
| | | | (Adjusted for ethnicity, age, parity, pregnancy-induced hypertension, infertility treatments, habitual abortions, previous perinatal death)
Hossain et al, 2004^103^ | Cross-sectional, clinic-based | Mymensingh Centre for Nuclear Medicine and Ultrasound | 34 PPs | [underlined: Prevalence of PP in those with prior CD]: 0.65%
Bangladesh | | | 2,536 subjects | [underlined: Prevalence of PP in those with prior VD]: 1.97%
2000 or 2001-2002
Makoha et al., 2004^104^ | Cross-sectional, hospital-based | Maternal and Children's Hospital clinical records | 162 PPs | [underlined: Prevalence of PP associated with the number of prior CDs:]
Saudi Arabia | | | 3,191 subjects | 1: 3.9%
1997-2000 | | | | 2: 3.2%
| | | | 3: 5.1%
| | | | 4: 6.9%
| | | | 5: 9.4%
| | | | 6+: 16.9% (P = 0.005 for 3–6+)
| | | | [underlined: OR for PP, relative to the quantity of prior CDs, compared to 3 prior CDs:]
| | | | COR: 4 vs.3: 1.4(0.8,2.2)
| | | | COR: 5 vs.3: 1.9(1.0,3.5)
| | | | COR: 6 vs.3: 3.8(1.9,7.4)
Gilliam et al., 2002^105^ | Case-control, | University of Illinois Perinatal Center and the Cook County Perinatal Center registries | 316 PPs | [underlined: OR for the number of prior CDs vs. 0:]
USA | hospital-based | | 2051 controls | [underlined: 1 vs. 0:] COR: 1.18(0.84,1.64)
1986-1989 | | | | [underlined: 2 vs. 0:] COR: 2.56(1.64,4.00)
| | | | [underlined: 3+ vs. 0:] COR: 3.62(1.45,9.10)
| | | | [underlined: OR for PP, relative to parity and prior CDs:]
| | | | [underlined: Parity 1, 1 prior CD:] AOR: 1.28(0.82,1.99)
| | | | [underlined: Parity 2, 2 prior CDs:] AOR: 1.95(1.13,3.39)
| | | | [underlined: Parity 3, 3 prior CDs:] AOR: 4.09(1.53,10.96)
| | | | [underlined: Parity 4, 4 prior CDs:] AOR: 8.76 (1.58, 48.53)
| | | | [underlined: Parity 4, 1 prior CD:] AOR: 1.72(1.12, 2.64)
Eniola et al., 2002^106^ | Case-control, hospital-based | Obafemi Awolowo University Teaching Hospitals Complex | 136 PPs | [underlined: OR for PP, relative to prior CD:]
Nigeria | | | 136 controls | COR: 5.3(2.3,12.5)
NR | | | | AOR: 4.7(1.9,11.4)
| | | | (Adjusted for age, education, gravidity, prior placenta previa, prior retained placenta, abortion)
Johnson et al., 2003^107^ | Case-control, hospital-based | 5 major obstetrics hospitals, identified potential subjects by ICD-9, then interviewed | 192 PPs | [underlined: Prevalence of prior CD among parous cases and controls:]
USA | | | 622 controls | Cases: 28.6%
1990-1992 | | | | Controls: 27.1%
Tuzovic et al., 2003^108^ | Case-control, hospital-based | Women's Hospital, Zagreb University School of Medicine | 202 PPs | [underlined: OR for PP, relative to prior CD:]
Croatia | | | 1004 controls | [underlined: 1 prior CD:] COR: 1.45(0.73,2.9)
1992-2001 | | | | [underlined: ≥ 1 prior CDs]: COR: 2.0(1.17,3.44)
| | | | [underlined: ≥ 2 prior CDs:] COR: 7.32 (2.1,25)
Laughon et al., 2005^109^ | Case-control, hospital-based | University of North Carolina hospital medical records, ultrasound database, perinatal database | 88 PPs | [underlined: OR for PP, relative to 1 prior CD:]
USA | | | 264 controls | OR 3.95(1.49,10.50)
2000-2003 | | | | [underlined: OR for PP, relative to each additional CD:]
| | | | OR 2.93 (1.60, 5.39)

CD, cesarean delivery; NR, not reported, PP placenta previa; VD, vaginal delivery; USA, United States of America.

Table 26 Description of study quality and inclusion and exclusion criteria for update of placenta previa

Author | Placenta Previas per 1,000 births | Inclusion Criteria | Exclusion Criteria | Study Question | Quality Rating
| | | | | Design (1–5) | Diagnosis (1–4)
Crane et al., 2000^99^ | 3.3 | All deliveries >20 weeks in the province of Nova Scotia | NR | To describe the maternal complications of previa, to describe the factors associated with complications | Logistic regression, adjusted for confounders 5 | Ultrasound, confirmed at delivery 4
Lydon-Rochelle et al., 2001^100^ | 5.2 | Primiparas with singleton live birth followed by a singleton birth during study period, in civilian hospital in Washington | Placental abruption or previa at first-birth | To evaluate the association between first birth cesarean delivery and placenta abruption or previa at second birth | Logistic regression, clear inclusion and exclusion criteria, looked for interaction and confounding 5 | ICD-9 code generated from delivery 3
Francois et al., 2003^110^ | 1.9 | Placenta previa or marginal previa | Low-lying placenta | To compare the occurrence of placenta previa between singleton and multiple gestation | No comparison group for prevalence of prior CD in deliveries without PP 2 | Confirmed at delivery 4
| | (≤ 1 cm from os) | > 1 cm from os
Dashe et al., 2002^98^ | NR | Complete or incomplete PP by ultrasound, liveborn singletons ≥ 25 weeks | Low lying placenta, women delivered vaginally for incomplete previas | To measure the persistence of placenta previa associated with diagnosis at increasing gestational age, to estimate effect of prior cesarean on previa persistence | Analyzed only the cohort of PP that had been diagnosed by ultrasound during pregnancy and confirmed at delivery = “persistent previa” Adjusted 3 | Ultrasound, confirmed at delivery 4
Rasmussenet al., 2000^102^ | 2.3 | NR | Women with only one delivery in study period, first delivery before study period, sibships with multiple births, those without complete information | To evaluate trends for placenta previa and whether previa is associated with previous pregnancies, cesarean deliveries, or socioeconomic factors | Logistic regression, adjusted for confounders, appropriate exclusions, but included PP in first delivery 4 | Unclear basis for diagnosis, assume at delivery given data source 3
Sheiner et al., 2001^101^ | 3.8 | All singleton deliveries with complete PP | NR | To determine the incidence of and the epidemiological risk factors and outcome for pregnancies complicated by placenta previa | Logistic regression, adjusted for confounders 5 | Ultrasound, confirmed at delivery 4
Hossain et al., 2004^103^ | NR | Presented for ultrasound at ≥ 28 wks, partial, marginal, or complete previas | Less than 28 wks gestation | To assess the prevalence of lower segment placenta (placenta previa) and its association with previous cesarean delivery, parity, and maternal age | Unclear exclusion criteria, no measures of significance given 2 | Ultrasound at 28 wks or later 3
Makoha et al., 2004^104^ | NR | Women with ≥ 1 CD with complete, partial or marginal PP | Prior uterine rupture, scar dehiscence, or rupture of CD scar; prior classical CD; any missing data from any indicator variable | To quantify maternal risk associated with cesarean delivery and to determine if a third cesarean is a threshold for increased morbidity | All patients had prior CD, addressed confounders, risk for potential bias in choice of subjects 3 | Ultrasound at 28–32 wks 3
Gilliam et al., 2002^105^ | NR | Partial or total previa, singleton pregnancy, multiparous | NR | To estimate the likelihood of placenta previa after multiple cesarean deliveries and to adjust for parity and the effect of other risks factors for previa | Adjusted for confounders 4 | Medical record generated from delivery 3
Eniola et al., 2002^106^ | NR | Controls: first delivery after case delivery without previa at >37wks, ≥ 2500 g, included twins | NR | To determine the risk factors for placental previa in Nigeria | Logistic regression, adjusted for confounders 4 | Confirmed at delivery 4
Johnson et al., 2003^107^ | NR | Singleton birth | Multiples, < 20 wks gestation, <500 g birth weight | To evaluate the risk of placenta previa associated with a history of induced abortion | No significance reported, OR not reported for CD and not adjusted 3 | ICD-9 screening followed by subject interview, but not specified criteria for diagnosis 3
Tuzovic et al., 2003^108^ | 3.8 | Complete, partial, marginal PP | Low-lying placenta, incomplete data, multiple gestations, placenta abruption, succenturiate placenta, placenta acreta | To evaluate potential risk factors and assess perinatal outcome for pregnancies complicated by placenta previa | Univariate analysis with stratification, presented crude OR 3 | Ultrasound, confirmed at delivery 4
Laughon et al., 2005^109^ | NR | Singleton pregnancies with ultrasound during second trimester, complete PP | Low-lying placenta | To determine whether the apparent increased risk in placenta previa associated with cesarean delivery is due to abnormal placentation or lower likelihood of resolution of previa diagnosed in second trimester | Case-control OR for PP at delivery were not described as adjusted, multiple sources of bias 3 | Ultrasound, confirmed at delivery 4

CD, cesarean delivery; ICD-9, International Classification of Diseases, 9th Revision; NA, not available; OR, odds ratio; PP, placenta previa; VD, vaginal delivery.

Adjusted odds ratios for placenta previa, relative to one or more prior cesarean deliveries ranged from 1.32 (95% CI, 1.04–1.68) to 4.7 (95% CI, 1.9–11.4). Two studies reported increased odds of placenta previa related to the number of previous cesareans and increased parity, as also demonstrated in the Faiz and Anath meta-analysis. The unadjusted odds ratio for six prior cesareans compared with three prior cesareans was 3.8 (95% CI, 1.9–7.4). The highest odds ratio reported was 8.76 (95% CI, 1.58–48.53) for women with parity 4 and four prior cesarean deliveries, but the confidence interval was very wide. One study demonstrated that placenta previa diagnosed during second trimester ultrasound was less likely to resolve in women with a previous cesarean than in women without a prior cesarean delivery.^98^ A single study of women with placenta previa, demonstrated a higher adjusted odds of hysterectomy in those with prior cesarean delivery than those without any prior cesarean.^99^

Subsequent stillbirth. We excluded studies of repeat cesarean delivery in accordance with our understanding that this systematic review was to focus on primary CDMR. Thus, our exclusion criteria yielded a pool of studies that is unlikely to be exhaustive for subsequent stillbirth. Only one study that met inclusion criteria for this systematic review also included data on subsequent stillbirths. It did not show a difference in rates of subsequent stillbirth among elective cesarean, emergency cesarean, and vaginal delivery.^70^

### Neonatal Outcomes

We examined all included studies for a range of neonatal outcomes summarized below in text and tables. Evidence Table 2 (Appendix C)^†^ provides the detailed information on all articles cited below. The approaches to determining relevance and grading the quality of individual studies are the same as for maternal outcomes (above).

† Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/cesarean/cesarreq.pdf.

Fetal mortality. We did not identify any studies with data on fetal mortality.

Neonatal mortality. A moderately relevant study of fair quality reported no neonatal mortality in either the elective cesarean delivery or the trial of vaginal delivery group, but it was underpowered to detect differences.^53,^ ^81^

The low relevance study reported neonatal deaths by mode of delivery.^81^ The authors reported death before discharge in 1 per 10,000 infants delivered spontaneously, 3 per 10,000 delivered by vacuum extraction, 5 per 10,000 delivered with the use of forceps, 6 per 10,000 delivered with the use of vacuum extraction and forceps combined, and 8 per 10,000 delivered by cesarean. The death rate did not differ significantly between infants delivered spontaneously and those delivered by vacuum extraction (OR = 1.5; 95% CI, 0.8–2.8, by forceps delivery (OR = 1.9; 95% CI, 0.60–5.4), or vacuum extraction combined with forceps delivery (OR = 2.6; 95% CI, 0.4–5.4). Significantly more deaths occurred among infants delivered by cesarean delivery than among those delivered spontaneously (OR = 3.7; 95% CI, 2.6–5.4). The death rate was the same for infants born by cesarean delivery during labor and for those born by cesarean delivery with no labor (0.8 per 1,000). These results did not adjust for underlying maternal or neonatal indications that might have dictated the choice of delivery route.

Unexpected (iatrogenic) prematurity. We found no studies that addressed unexpected (iatrogenic) prematurity as an outcome. The only valid method to determine whether the problem of unexpected prematurity exists is to analyze studies that included cesarean deliveries performed solely because of maternal choice in comparison with studies involving other modes of delivery. Because we did not identify articles that received a high relevance rating (specifically, maternal choice cesarean), we cannot comment on this outcome.

Other studies we reviewed may have included some “elective” cesarean deliveries. However, all had some maternal or neonatal indication that led to cesarean, and potentially a preterm delivery, such as placenta previa, breech, hypertension, or fetal distress; they would not provide an appropriate base on which to comment on this particular outcome.

Respiratory morbidity. Of the eight studies (nine articles) that included respiratory morbidity as an outcome, we rated four as moderately relevant, all of fair quality,^47,^ ^48,^ ^51^–^53^ and four as low relevance.^65,^ ^77,^ ^80,^ ^81^ (Table 27).

Table 27 Respiratory morbidity

Author, Year | Measure | Outcomes for Comparison Groups | | | | | | | | Statistical Test Results
Relevance/ Quality Rating
Levine et al., 2001^47^ | | Elective CD | VD(ref grp) | All CD
Moderate/Fair | TTN | 3.10% | 1.10% | 3.50% | | | | | | P < 0.001
| OR (95% CI) | 2.8 (2.1; 3.8) | 1.0 | 3.3 (2.6; 3.9)
| RDS | 0.20% | 0.16% | 0.47% | | | | | | Only all CD vs vaginal is significant
| OR (95% CI) | 3.0 (1.6; 5.3) | 1.0 | 1.3 (0.; 3.8)
| PPH | 0.37% | 0.08% | 0.40% | | | | | | P < 0.01
| OR (95% CI) | 4.6 (1.3; 11) | 1.0 | 4.9 (2.2; 8.8)
Morrison et al., 1995^48^ | | Prelabor CD | VD(ref grp) | CD in labor
Moderate/Fair | TTN | 2.26% | 0.41% | 0.84% | | | | | | NR
| RDS | 1.28% | 0.11% | 0.38% | | | | | | NR
| RDS+TTN | 3.55% | 0.51% | 1.22%
| OR (95% CI) | 6.8 (5.2; 8.9) | 1.0 | 2.3 (1.6; 3.5)
Zanardo et al., 2004;^53^ | | Elective CD | VD (ref grp)
Zanardo et al., 2004^52^ | TTN | 0.93% | 0.85% | | | | | | | NR
Moderate/Fair | RDS | 2.26% | 0.39% | | | | | | | P < 0.01
| OR (95% CI) | 2.60 (1.35; 5.90) | 1.0
| Need for positive pressure ventilation (PPV) | 3.4% | 1.4% | | | | | | | P < 0.01
| OR (95% CI) | 2.05 (1.25; 5.67) | 1.0
Schindl et al., 2003^51^ | | Elective CD | Intended VD
Moderate/Fair | Respiratory adaptation problems | 0.70% | 0.00% | | | | | | | NR
Dani et al., 1999^65^ | | Elective CD | VD (ref grp) | AVD | Emergency CD
Low/Not rated | RDS | 1.43% | 0.49% | 0.06% | 26.65%
| OR (95% CI) | 1.88 (1.42; 2.48) | 1.0 | NR | OR: 3.46 (2.69; 4.44) | | | | | P < 0.0001
| TTN | 1.42% | 0.51% | 0.80% | 14.66%
| OR (95% CI) | 1.86 (1.48; 2.33) | 1.0 | NR | 2.86 (2.25; 3.63) | | | | | P < 0.0001
Sutton et al., 2001^80^ | | Elective CD | VD (ref grp) | Forceps Delivery | Emergency CD
Low/Not rated | RDS | NR | NR | NR | NR | | | | | Significantly different
| OR (95% CI) | 2.64 (1.42; 4.90) | 1.0 | 4.47 (2.11; 9.44 | 4.07 (2.13; 7.78)
Towner et al., 1999^81^ | | Unlabored CD | Spontaneous vaginal (ref grp) | Vacuum extraction | Forceps | Forceps and Vacuum | Labored CD | Labored CD with Attempt at Vacuum or Forceps | Labored CD, no Attempt at Vacuum or Forceps
Low/Not rated | Mechanical Ventilation | 0.71 | 0.258 | 0.39 | 0.45 | 0.50 | 1.03 | 1.56 | 1.02 | Significantly different
| OR (95% CI) | 2.8 (2.4; 3.3) | 1.0 | 1.5 (1.3; 1.8) | 1.8 (1.4; 2.3) | 1.9 (1.1; 3.4) | OR: 4 (3.6; 4.3) | OR: 6 (4.3; 8.3) | OR: 2.6 (2.2; 3.0)
Rubaltelli et al., 1998^77^ | | Elective CD | VD (ref grp) | Forceps (Subset of Vaginal) | Emergency CD
Low/Not rated | TTN | 1.5% | NR | 3.8% | 4.2% | | | | | P < 0.0001 for: Elective CD compared to vaginal

TTN, transient tachypnea of the newborn; RDS, Respiratory distress syndrome; PPH, persistent pulmonary hypertension; AVD, assisted vaginal delivery; ref grp, reference group; NS, not significant; NR, not reported; OR, odds ratio; CI, confidence interval.

Studies generally defined respiratory morbidity clinically as transient tachypnea of the newborn (TTN), respiratory distress syndrome (RDS), and persistent pulmonary hypertension (PPH). Our search strategy required a comparison of planned cesarean with planned vaginal delivery; as a consequence, our review did not include studies of meconium aspiration syndrome (MAS). One study reported “respiratory adaptation problems” without further explanation.^51^ However, some studies reported surrogate outcomes such as neonatal intensive care unit (NICU) admission or need for positive pressure ventilation (PPV).^53^

The inverse relationship between respiratory morbidity and gestational age is well known. However, two of the eight studies included extremely premature infants under 27 weeks' gestation;^65,^ ^77^ a third study included infants with gestational age ≥ 35 weeks;^47^ and a fourth study of an administrative database included infants between 2,500 and 4,000 grams but did not report gestational age.^81^ The remaining four studies included infants ≥ 37 weeks.^48,^ ^51^–^53,^ ^80^

Four studies provide a subanalysis of outcomes by gestational age.^48,^ ^52,^ ^53,^ ^77,^ ^80^ No study reported on severity of respiratory morbidity by gestational age.

With respect to the four moderately relevant studies, three included TTN and RDS as outcomes.^47,^ ^48,^ ^52,^ ^53^ Additionally, the Levine study included PPH,^47^ and the Zanardo study reported the incidence of PPV.^53^ Two moderately relevant studies provided a subanalysis by gestational age.^48,^ ^52,^ ^53^

Three of these studies reported a significantly higher risk of respiratory morbidity associated with elective cesarean delivery than with vaginal delivery.^47,^ ^48,^ ^52,^ ^53^

Both moderately relevant studies with gestational age subanalyses showed a reduction in respiratory morbidity associated with advancing gestational age.^48,^ ^52,^ ^53^ One study found that the risk of RDS but not TTN was significantly higher with “elective” cesarean from 37 weeks through 38 weeks and 6 days gestation.^52,^ ^53^ However, neither RDS or TTN was significantly different from 39 weeks through 41 weeks and 6 days gestations.

The other moderately relevant study combined RDS or TTN requiring an NICU admission into a composite measure of respiratory morbidity in the subanalysis for gestational age.^48^ The rate of respiratory morbidity was significantly higher among prelabor cesarean deliveries than among vaginal deliveries from 37 weeks through 39 weeks and 6 days gestation, but the rate did not differ significantly between these groups thereafter.

The fourth moderately relevant study compared “elective cesarean” with intended vaginal delivery. The authors reported a single case of “respiratory adaptation problems” in 147 elective cesareans, but they did not report any statistical testing.^51^

We also reviewed four low relevance studies. Two reported on PPV alone.^80,^ ^81^ Two studies provide a subanalysis by gestational age.^77,^ ^80^

Both studies limited to PPV found a higher risk of PPV among prelabor cesareans than among vaginal deliverues.^80,^ ^81^ Indications for PPV in this study included TTN, RDS, MAS, pulmonary hypertension, infection without neurological symptoms, pneumothorax, amniotic fluid aspiration, and pneumomediastinum. Of these studies, only one provided a subanalysis by gestational age, finding a significantly higher risk for PPV at gestational age of 37 to 38 weeks compared with >38 weeks.^80^

Two of the four low relevance studies defined respiratory morbidity as RDS or TTN.^65,^ ^77^ Both studies showed a higher risk of TTN among “elective” cesarean deliveries than among vaginal deliveries. One study showed a higher risk of RDS among “elective” cesareans than among vaginal delivery.^65^ The other study did not report overall incidence rates of RDS by mode of delivery, but in the subanalysis by gestational age, the investigators showed declines in the rates of RDS and TTN with increasing gestational age.^77^

Overall, the results showed a higher risk of respiratory morbidity from TTN or RDS among elective cesarean births than among vaginal delivery and a consistent reduction in risk with advancing gestational age approaching equality at 39 through 40 weeks.

We further analyzed these studies to assess the effect of labor on the incidence of respiratory morbidity. One of four studies that compared TTN and RDS between prelabor and labored cesarean deliveries showed a lower risk of respiratory morbidity in labored cesarean deliveries.^48^ However, the three remaining studies showed a higher risk of respiratory morbidity in labored cesarean deliveries.^47,^ ^80,^ ^81^ We cannot determine whether the higher riskof respiratory morbidity associated with labored cesarean deliveries in these three studies is due to TTN, RDS, or MAS. Similarly, we can not determine whether the higher rate can be attributed to a higher rate of emergency cesareans for complications related to prematurity because the data are not presented in a manner that allowed us to answer this question.

We did not identify any studies that compared MAS between modes of delivery. Two studies that focused on TTN and RDS excluded MAS.^47,^ ^48^ Others reported on positive pressure ventilation for indications that included MAS.^77,^ ^80^ An accurate and comprehensive assessment of neonatal respiratory morbidity would ideally account for TTN, RDS, and MAS by planned route of delivery and separated by gestational age.

Transition. One study of low relevance that reported on feeding difficulty as a measure of transition found a higher risk with all modes of delivery except for spontaneous vaginal delivery.^81^ The risk was not significantly higher for vacuum, forceps, vacuum or forceps, or cesarean “during labor after a failed attempt at vaginal delivery.” By contrast, it was significantly higher after cesarean “during labor with no attempt at vaginal delivery” and cesarean “without labor.” This study did not distinguish between planned and unplanned cesarean deliveries. Women who had a cesarean delivery without labor or with labor, with no attempt at vaginal delivery, may have had maternal or neonatal indications for emergency cesarean delivery that also influenced neonatal transition.

Neonatal asphyxia and encephalopathy. Encephalopathy is a broad category. We limited our review to outcomes that were associated with hypoxic-ischemic encephalopathy. Two studies included outcomes related to neonatal encephalopathy, one of moderate relevance and fair quality,^37^ and one of low relevance.^81^ The moderately relevant study defined neonatal encephalopathy as either seizures alone or any two of the following conditions that lasted for longer than 24 hours: abnormal consciousness, difficulty maintaining respiration (of presumed central origin), difficulty feeding (of presumed central origin), or abnormal tone and reflexes. It found a significantly lower risk of newborn encephalopathy associated with “elective cesarean section” than with spontaneous vaginal delivery (OR = 0.17; 95% CI, 0.05–0.56. Both instrumental vaginal delivery and emergency cesarean delivery were associated with significantly higher rates of newborn encephalopathy than spontaneous vaginal delivery (respectively, OR = 2.34; 95% CI, 1.16–4.70, and OR = 2.17, 95% CI, 1.01–4.64).

The low relevance study used Current Procedural Terminology (CPT and ICD-9 codes for convulsions and central nervous system (CNS) depression as outcomes. The authors found a higher risk of both convulsions and CNS depression among “unlabored cesarean sections” than among spontaneous vaginal delivery. However, these results were significant only for CNS depression (OR, 2.2; 95% CI,1.3–3.6).^81^ This study showed a significantly higher risk of both convulsions and CNS depression with vacuum, vacuum and forceps, and cesarean during labor than with spontaneous vaginal delivery.

Intracranial hemorrhage. One low relevance study reported on subdural or cerebral hemorrhage, intraventricular hemorrhage, and subarachnoid hemorrhage among various modes of delivery.^81^ Overall, the hemorrhage rates were similar between spontaneous vaginal delivery and “prelabor” cesareans. The results showed a consistently higher risk for all three injuries with vacuum, forceps, vacuum and forceps, and cesarean during labor but were not universally statistically significant.

Facial nerve injury. One low relevance study specifically addressed facial nerve injury through use of ICD-9 and CPT code data.^81^ The study found no significant differences in the incidence of facial nerve injury associated with vacuum (OR = 1.7; 95% CI, 0.9–2.1) or “prelabor” cesarean delivery (OR = 1.5; 95% CI, 0.8–2.6) compared with facial nerve injury incidence associated with spontaneous vaginal delivery. However, the study found a significantly higher rate of facial nerve injury among forceps delivery (OR = 13.6; 95% CI, 10.0–18.4), the composite attempt at vacuum and forceps (OR = 8.5; 95% CI, 3.9–18.0), and the subgroup of cesareans that failed an attempt at vaginal delivery with either vacuum or forceps (OR = 3.8; 95% CI 1.2–12.1).

Brachial plexus injury. One low relevance study reported on brachial plexus injury related to mode of delivery.^81^ The rate of brachial plexus injury was significantly higher in vacuum, forceps, and the combined attempt at vacuum and forceps than in spontaneous vaginal delivery (respectively: OR = 2.3; 95% CI, 1.8–2.9; OR= 3.2; 95% CI, 2.3–4.6; and OR = 6.0; 95% CI, 3.3–10.7). It was significantly lower in cesareans overall as well as in cesareans performed “during labor” than in spontaneous vaginal delivery (respectively, OR = 0.4; 95% CI, 0.3–0.5; OR = 0.2; 95% CI, 0.1–0.4). The rate was lower in “prelabor” cesarean deliveries than in spontaneous vaginal delivery, (OR = 0.5; 95% CI, 0.3–1.0).

Fetal laceration. Two moderately relevant studies of poor quality included fetal lacerations as a neonatal outcome by mode of delivery.^28,^ ^40^ One study reported on mild, moderate, and severe fetal lacerations among “scheduled,” “unscheduled,” and “emergency” cesarean deliveries.^40^ The study found a significantly higher rate of fetal lacerations among emergency cesareans (OR = 1.7) than among either scheduled cesareans (OR = 0.34) or unscheduled cesareans (OR = 0.57). The authors calculated the odds ratios by comparing the odds for each of the three categories with the composite odds for all fetal lacerations among all three types of cesareans. All moderate and severe fetal lacerations were in the emergency cesarean group.

The other study compared outcomes among “primary elective” cesareans, “primary acute” cesareans, and “secondary acute” cesareans.^28^ This study reported a “fetal complication” rate of 1.3 percent. The authors noted that the “most frequent fetal complication was an accidental incision of the fetal skin while opening the uterus” (p. 4).^28^ The rates of fetal complication (which we interpret to mean primarily fetal laceration) by mode of delivery in descending order of incidence were “secondary acute” cesarean (1.5%), “primary acute” cesarean (1.4%), and “primary elective cesarean (0.8%).

Neonatal length of stay. One study of moderate relevance and fair quality reported on length of hospital stay in two articles.^52,^ ^53^ The mean length of stay was higher in the “elective” cesarean group (6 days) than in the vaginal delivery group (4 days). The authors did not report statistical test results.

Long-term bonding, behavioral issues, and physical development. We found no studies that addressed any of these issues.

## Key Question 3 What factors affect the magnitude of the benefits and harms identified in KQ 2?

We limited this key question to studies comparing planned CDMR with planned vaginal delivery and to studies assessing effect modifiers in planned CDMR. The outcomes of interest initially were those specified for KQ 2.

We did not include studies that evaluated effect modifiers exclusively in populations with planned vaginal delivery (i.e., studies without planned CDMR as a control group). An extensive body of literature exists on effects of factors such as comorbidities, settings, patient characteristics, and many others on the outcomes of vaginal delivery. Effect modifiers for vaginal deliveries, however, were beyond the scope of this review.

We defined effect modifiers as maternal or fetal characteristics that modify the effect of either planned CDMR or planned vaginal delivery on an outcome of interest. In addition, we included time of day of delivery, physician experience, quality of nursing, labor support, type of delivery, pregnancy dating, and level of perinatal care as general characteristics. Table 28 summarizes effect modifiers that we considered of primary interest.

Table 28 Potential effect modifiers for planned CDMR and planned vaginal delivery

Maternal Characteristics | Fetal Characteristics | General
Maternal age | Sex | Time of day of delivery
Parity | Fetal size | Physician experience or specialty
Race or ethnicity | Gestational age | Labor support
Body mass index | | Quality of nursing
Socioeconomic status | | Level of perinatal care
Medical characteristics | | Type of labor
| | Pregnancy dating

We did not regard differences in interventions, such as antibiotic prophylaxis or operation techniques, as being effect modifiers. Differences in outcomes based on interventions are attributable to cause and effect relationships rather than to interacting variables.

Only five studies met our inclusion criteria and assessed factors that have the potential to alter the benefits and harms of planned CDMR or planned vaginal delivery.^48,^ ^53^–^55,^ ^82^ We did not find any evidence for most of the KQ 2 outcomes of interest. The outcomes reported in the existing evidence were limited to fetal respiratory morbidity, infectious morbidity, and urinary incontinence.

We rated three studies as moderately relevant^53^–^55,^ ^82^ and one as being of low relevance.^48^ Only two studies controlled for confounding factors by employing a multivariate regression model to determine effect modifiers.^54,^ ^82^ Results of all remaining studies are crude estimates, uncontrolled for confounders. Characteristics of included studies are presented in Table 29 (in order by relevance and then quality rating).

Table 29 Characteristics of included studies for key question 3

Author, Year | Study Design Population | Sample Size | Definition of “Elective Cesarean” | Definition of Planned Vaginal Delivery | Outcome of Interest | Adjusted for Confounders
Relevance, Quality | | | | | Effect Modifier
Myles et al., 2002^54^ | Retrospective cohort study | 214 | Patients who had reassuring fetal heart tones and did not have active labor or rupture of the membranes prior to surgery | Not applicable | Post-cesarean infectious morbidity | Yes
Moderate | Patients with elective cesarean | | | | BMI, race
Good
van den Berg et al., 2001^55^ | Retrospective cohort study | 433 | Surgery was performed after 37th week of pregnancy without compli-cating factors influencing the timing of delivery and without preceding labor | Not applicable | Neonatal respiratory distress | No
Moderate | Patients with elective cesarean | | | | Gestational age
Fair
Zanardo 2004^53^ | Retrospective cohort study | 1,284 | Delivered before onset of labor | Not applicable | Neonatal respiratory distress / gestational age | No
Moderate | Patients with elective cesarean
Fair
Morrison et al., 1995^48^ | Retrospective cohort study | 36,461 | Before onset of labor | Not reported | Neonatal respiratory distress | No
Low | All deliveries | | | | Gestational age
Not rated
Wilson et al., 1996^82^ | Cross-sectional survey | 1,505 | Not reported | Not reported | Urinary incontinence | Yes
Low | Women 3 months postpartum | | | | Pelvic floor exercises, Body mass index
Not rated

Three retrospective cohort studies assessed the influence of gestational age on neonatal respiratory distress after “elective cesarean.”^48,^ ^53,^ ^55^ Populations were not limited to those with CDMR. All three studies determined gestational age using chart information on menstrual history and ultrasound data obtained in the first trimester, but their definitions of “elective cesarean” and neonatal respiratory distress varied. Three moderately relevant studies^48,^ ^53,^ ^55^ included patients who had “elective cesarean delivery” after 37 weeks of pregnancy in the absence of complicating factors influencing the timing of delivery and neonatal outcomes. One of these two studies, however, included only patients with spinal anesthesia.^53^ By contrast, the third study, rated as having low relevance, did not exclude patients with comorbidities or patients undergoing general anesthesia.^48^ All three studies based respiratory distress on the presence of clinical symptoms of respiratory distress such as tachypnea, retractions, nasal flaring, or cyanosis. In addition, two studies used radiographic features of RDS and TTN as additional criteria.^48,^ ^53^

Despite these differences, results consistently presented a decrease of respiratory morbidity with increasing gestational age. Table 30 and Figure 5 summarize the prevalence of neonatal respiratory morbidity following “elective cesarean section” at different gestational ages. Cuzick's test for trend indicated a statistically significant trend for the combined data of the included studies (P = 0.012). These findings are also consistent with a Dutch study published in English as an abstract only.^111^

Table 30 Number of cases (and percentage) of neonatal respiratory morbidity by gestational week following elective cesarean delivery

Gestational Age | Morrison et al.^48^ | van den Berg et al.^55^ | Zanardo et al.^53^
37 weeks to 37 weeks, 6 days | 27 of 366 (7.4%) | 8 of 95 (8.4%) | Not reported
38 weeks to 38 weeks, 6 days | 45 of 1,063 (4.2%) | 8 of 183 (4.4%) | 32 of 765 (4.2%) (total for less than 38 weeks, 6 days
39 weeks or more | 11 of 912 (1.2%) | 1 of 55 (1.8%) | 9 of 519 (1.7%)

Figure 5. Prevalence of neonatal respiratory morbidity by gestational week following elective cesarean or vaginal and labored cesarean

Only one study (low relevance) provided data on the effect of gestational age on neonatal respiratory morbidity for patients with vaginal delivery and labored cesarean.^48^ Gestational age appeared to have a lesser effect on neonatal respiratory morbidity in combined patients with vaginal delivery or labored cesarean delivery. In this population, in gestational week 37, only 1.68 percent of neonates suffered from respiratory morbidity. The prevalence declined to 0.48 percent for deliveries at or after week 39.

A different retrospective cohort study (moderate relevance) did not find gestational age to be a risk factor for post-cesarean infectious morbidity.^54^ In this study, after multivariate analysis BMI and race were the only risk factors that remained statistically significant for post-cesarean infectious morbidity in patients undergoing “elective cesarean.” The relative risk for postoperative infectious morbidity in obese patients was 1.6 (95% CI, 1.2–2.0). In addition, black patients had a significantly higher rate of infection (RR not reported). Other factors such as physician's experience, incision type, maternal age, and prophylactic antibiotics were statistically significant in the univariate analysis but did not maintain statistical significance in the multivariate model.

A cross-sectional survey (low relevance; response rate 70.5 percent) of 1,505 women 3 months after delivery examined the relation between obstetric factors and incontinence.^82^ For both vaginal and cesarean deliveries, combined pelvic floor exercises significantly reduced the prevalence of incontinence at 3 months (OR = 0.6; 95% CI, 0.4–0.9). Prepregnancy BMI significantly increased the risk of incontinence (OR = 1.07; 95% CI, 1.04–1.10), but the clinical significance of this finding might be questionable. Results were not stratified by planned CDMR and planned vaginal delivery. However, women with previous incontinence had higher rates of incontinence at 3 months than those without previous incontinence (elective cesarean: 38.1 percent vs. 8.8 percent; vaginal delivery: 28.2 percent vs. 24.8 percent).