# Methods

In this chapter, we document the procedures that the RTI International-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) used to develop this comprehensive evidence report on cesarean delivery on maternal request (CDMR). It will be used as the core background document for an upcoming State of the Science (SOS) conference sponsored by the Office of Medical Applications Research (OMAR) of the National Institutes of Health (NIH).

We first describe our strategy for identifying articles relevant to our four key questions, our inclusion/exclusion criteria, and the process we used to abstract relevant information from the eligible articles and generate our evidence tables. We also discuss our criteria for grading the quality of individual articles and the strength of the evidence as a whole. Finally, we explain the peer-review process.

## Literature Review Methods

### Inclusion and Exclusion Criteria

Our inclusion and exclusion criteria are documented in Table 3. As noted in Chapter 1, we limited our searches to articles published in or after 1990 because of the significant advances in operative techniques, anesthesia, availability of antibiotics, and neonatal care over the past several decades that have resulted in a decline in maternal and neonatal mortality.^1^ We also restricted our searches to developed countries so that we could have comparable data on the standard of care. Based on recommendations from the Technical Expert Panel (TEP), we tracked citations from Brazil, which has long been documented to have high rates of cesarean deliveries;^29,^ ^30^ however, no study from Brazil met our inclusion criteria.

Table 3 Inclusion/exclusion criteria for cesarean delivery upon maternal request

Category | Criteria
Study population | Humans, females, all races, ethnicities, and cultural groups
Study settings and geography | Developed nations: United States, Canada, United Kingdom, Western Europe, Japan, Australia, New Zealand, Israel
Time period | 1990-2005
Publication languages | English only
Sample size | Sample sizes must be appropriate for the study question addressed in the paper.
| RCTs: 50 or more participants
| Observational studies: 100 or more participants
Admissible evidence (study design and other criteria) | Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results
| Eligible study designs include RCTs: double-blinded and single-blinded; observational studies: prospective and retrospective cohort studies, case control studies, and cross-sectional; and meta-analyses.
| Ineligible study designs include single case reports or small case series.
| Patient populations must be of reproductive age or older.
| KQ 1 and KQ 2
| All studies must include a comparison of planned cesarean deliveries with planned vaginal deliveries.

Because our searches focused on the comparison of planned cesarean delivery to planned vaginal delivery, we recognized that we were unlikely to capture relevant studies on placental implantation abnormalities. On the advice of our TEP, our summary of this topic consists of an update of a recent systematic review on placenta previa.^31^ Because of time and resource limitations, however, we could not address other placental implantation abnormalities such as accreta (abnormally firm attachment of the placenta to the uterine wall) and percreta (extension of the placenta through the entire wall of the uterus) that may also be associated with a history of cesarean deliveries.

Similarly, our search strategy focused on primary cesarean deliveries, excluding studies limited to repeat cesarean deliveries. For that reason, we could not capture studies that examined outcomes such as uterine rupture related to subsequent deliveries in women with prior cesarean deliveries. Again on the advice of our TEP, we address this important topic using information from an update of a recent review on vaginal birth after cesarean (VBAC).^32^

We excluded studies that (1) did not report on women of reproductive age; (2) were published in languages other than English (given the available time and resources); (3) did not report information pertinent to the key clinical questions; (4) had fewer than 50 subjects for randomized controlled trials (RCTs) or 100 subjects for observational studies; and (5) were not original studies. Additionally, and in consultation with the TEP, we excluded studies that did not include data on both planned cesarean delivery and planned vaginal delivery for KQ 1 and KQ 2. As a consequence of this search strategy, we cannot address outcomes from vaginal delivery alone, without reference to a cesarean delivery comparison group. A review of the outcomes from vaginal delivery alone was beyond the scope and resources available. As a consequence of this limitation, we are not able to address modifiers of vaginal deliveries alone in KQ 3.

We also excluded studies that reported on an undefined group of cesarean deliveries; many of the maternal and neonatal indications that would have been included were so highly associated with significant morbidity as to preclude any meaningful extrapolation to CDMR.

### Literature Search and Retrieval Process

Databases. We used multifaceted search strategies to include current and valid research on the key questions. We used standard electronic databases: MEDLINE^®^, Cochrane Collaboration resources, and Embase. We also hand-searched the reference lists of relevant articles to make sure that we did not missing any relevant studies. We consulted with the TEP about any studies or trials that are currently under way or that may not be published yet.

Search terms. Based on the inclusion/exclusion criteria above, we generated a list of Medical Subject Heading (MeSH) search terms (Appendix A).^*^ Our TEP also reviewed these terms to ensure that we were not missing any critical areas, and this list represents our collective decisions as to the MeSH terms used for all searches. We needed to conduct several focused searches to capture a wide pool of relevant studies because the term “cesarean delivery on maternal request” is not a standard indexing term (Table 4). The SOS Conference panel had set priorities for outcomes of interest, and those guided our selection of the specific outcomes for this review. Our initial searches did not capture key citations dealing with neonatal outcomes; based on the advice of the TEP, we conducted additional searches to capture relevant citations.

* Appendixes and Evidence Tables for this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/cesarean/cesarreq.pdf

Table 4 Focused searches and unduplicated results

Focused Searches | Unduplicated Results
Initial search on elective cesarean delivery and similar terms in MEDLINE^®^, Cochrane Collaboration resources, and Embase | 926
Additional search on neonatal outcomes limited to RCTs | 48
Additional search on neonatal outcomes limited to observational studies | 93
Additional search on adverse events in neonates | 90
Additional searches on placenta previa | 116
Additional search on update of Faiz and Ananth's review of placenta previa^31^ | 98
Handsearch | 34
Total | 1,406

Figure 3 presents the yield and results from our search, which we conducted from April through June 2005. Beginning with a yield of 1,402 articles, we retained 65 articles comprising 62 studies that we determined were relevant to address our key questions and met our inclusion/exclusion criteria (Figure 4). Peer reviewers suggested several additional citations, of which 4 articles comprised 3 new studies that did not duplicate ones we had already identified and excluded. We reviewed titles and abstracts of the remaining suggestions against the basic inclusion criteria above; we retained relevant articles, all published after our search cutoff date, and used them as appropriate in the discussion in Chapter 4.

Figure 4. Disposition of articles for cesarean on maternal request article disposition

Article selection process. Once we had identified articles through the electronic database searches, review articles, and bibliographies, we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated the abstracts for inclusion or exclusion, using an Abstract Review Form (see Appendix B). If one abstractor concluded that the article should be included in the review, we retained it. The group included four physicians—Anthony Visco, MD (Scientific Director); Katherine Hartmann, MD, PhD (Senior Advisor); Jennifer Wu, MD; and Gerald Gartlehner, MD, MPH (Study Coordinator). It also included one health services researcher—Meera Viswanathan, PhD (Study Director) and three epidemiologists—Michele Jonsson Funk, PhD, Rachel Palmieri, BS, and Shauna Hay, BS.

Four hundred and ninety articles required full review because of missing or uninformative abstracts. For the full article review, one reviewer read each article and decided whether it met our inclusion criteria, using a Full Text Inclusion/Exclusion Form (Appendix B). Articles excluded at the full-article review stage and reasons for their exclusion are listed in Appendix D.

## Literature Synthesis

### Development of Evidence Tables and Data Abstraction Process

The staff members who conducted this systematic review jointly developed the data abstraction tables (Appendix B ^†^) and evidence tables (Appendix C). We designed the tables to provide sufficient information to enable readers to understand the studies and to determine their quality; we gave particular emphasis to essential information related to our key questions. The format of the evidence tables was based on successful designs used for prior systematic reviews.

† Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/cesarean/cesarreq.pdf.

We trained abstractors in entering data into the tables by having them abstract several articles and then reconvening as a group to discuss the utility of the table design. The abstractors repeated this process through several iterations until they decided that the tables included the appropriate categories for gathering the information contained in the articles.

All team members shared the task of initially entering information into the data abstraction forms. Another member of the team also reviewed the articles and edited all initial table entries for accuracy, completeness, and consistency. The two abstractors reconciled all disagreements concerning the information reported in the abstraction forms. The full research team met regularly during the article abstraction period and discussed global issues related to the data abstraction process.

We then entered the data from the abstraction forms into evidence tables and once again checked for consistency and accuracy.

The final evidence tables are presented in their entirety in Appendix C. Studies are presented in the evidence tables alphabetically with the last name of the first author. A list of abbreviations and acronyms used in the tables appears at the beginning of that appendix.

### Quality and Strength of Evidence Evaluation

Rating the relevance of individual articles. The vast majority of studies reported results on actual route of delivery rather than planned route of delivery (intent to treat), which led to the limitations introduced in Chapter 1. Initial review of the literature demonstrated several ambiguous definitions that presented the authors of this review with several challenges. The use of the phrase “elective cesarean delivery” was particularly problematic because of its wide range of definitions. Some investigators used the term “elective” to refer to situations in which a vaginal delivery was contraindicated, such as with placenta previa. Others used it to describe situations in which vaginal delivery could have been attempted, such as with breech presentation, active herpes simplex virus, or repeat cesarean delivery. Still others used it but failed to define it further, precluding reviewers from understanding either the labor status or the indications for the cesarean.

We found it impossible to arrive at any meaningful summary of the literature without explicitly addressing the issues of how to characterize the groups in these studies and, thus, how to categorize the studies themselves. To address this ambiguity, we developed a four-tier classification system of relevance to CDMR based on the following criteria: (1) whether studies analyzed outcomes by planned route of delivery (trials of route of delivery); (2) whether CDMR was included as a comparison group (high relevance); (3) whether comparison groups comprised planned cesareans (moderate relevance), and (4) whether studies involved undefined “elective” or a mix of planned and unplanned, unlabored cesareans (low relevance).

Table 5 presents relevance ratings for all studies included in this review. The first three categories of relevance—high (H), moderate (M), and low (L)—are explained below.

Table 5 Summary relevance rating

| Degree of Relevance to CDMR and Rating | Definition of Category | Number of Studies Included for
| | | KQ 1 | KQ 2* | KQ 3
H | High (H) | Cesarean delivery on maternal request | 1^33^ | 0 | 0
M | Moderate (M) | Cesarean delivery planned for maternal and/or neonatal indications and can include both labored and unlabored | 3^34^–^36^ | 16†^28^,^37^–^53^ | 4^48^,^53^–^55^
L | Low (L) | Unspecified “elective” cesarean delivery, can be a mix of planned and unplanned deliveries that are either unlabored or do not give clear indication of labor status | 9^3^,^56^–^63^ | 19^64^–^82^ | 1^82^
| Trials of delivery for neonatal indications (T) | Intended mode of delivery (planned cesarean versus planned vaginal) | 0 | 2†^18^,^20^,^83^,^84^ | 0

* Excludes studies from the placenta previa update

† Includes multiple articles from a single study

Because we view the first criterion above as the ideal comparison, we assigned trials of routes of delivery,^‡^ comparing prospectively assigned planned routes of delivery for breech presentation, a relevance rating of “T” to distinguish them from other studies that dealt with actual delivery routes. However, we note that trials of route of delivery for breech presentation are limited in their relevance to CDMR for primarily vertex (head first) presentation for four main reasons: (1) they cannot be included in a summary of neonatal outcomes because the confounding effect of breech presentation in the sample of women could negatively influence neonatal outcomes; (2) the extent to which cesarean for breech serves as an accurate surrogate for CDMR is unclear because of uncertainty as to whether the time period between presentation in labor and cesarean delivery for breech is similar to that for CDMR; (3) the risk that a cesarean would be performed in the planned vaginal breech delivery group is likely to be significantly higher than if the fetus were vertex; and (4) the inclusion of multiparous patients, including some with previous cesarean deliveries, results in significantly different risks and benefits than for the central focus of this review, namely, primary CDMR.

‡ These studies of trial of routes of delivery assigned women to either planned vaginal delivery or planned cesarean delivery (often called “trials of labor”), but did not require a randomized design.

Many studies included a combination of planned and unplanned, labored and unlabored cesarean births for maternal or neonatal indications in an “elective” cesarean group. Using our relevance classification scheme, we sorted this range of studies into groups of literature with high, moderate, and low relevance to CDMR. Studies with a cesarean delivery group performed solely on maternal request, without any maternal or neonatal indications, were considered the most highly relevant to the central question of this systematic review; we assigned them a relevance rating of A. As expected, however, we found no such published studies for KQ 2 and KQ 3 and only one such study for KQ 1.

Studies in the moderately relevant category were all planned cesareans, but they included labored, unlabored, or a mix of labored and unlabored cesarean deliveries. Some studies included cesareans planned and performed, before labor, for maternal or neonatal indications (or both). Such studies may understate the risk of CDMR, because an accurate assessment of outcomes should include both labored and unlabored cesareans when comparison groups are separated by intent; that is, planned CDMR versus planned vaginal delivery. The group also included studies involving planned and performed cesareans for maternal and/or neonatal indications but with a mix of labored and unlabored deliveries. These may overestimate the risk of planned CDMR if the rate of labored cesareans in the study exceeds the rate of labor before scheduled delivery in a population considering CDMR.

Studies of low relevance did not define the “elective” cesarean delivery group, or they included a mix of planned and unplanned unlabored cesarean deliveries. The chief uncertainty concerns the degree to which the “elective” cesarean delivery group included emergency or labored cesareans. Emergency indications that would potentially be included in such a category include abruption, maternal trauma, and fetal distress; each could increase maternal or neonatal morbidity considerably.

Rating the quality of individual articles. We developed our approach to assessing the quality of individual articles (see Appendix B for Quality Rating Forms) based on the domains and elements for RCTs and nonrandomized observational studies recommended in the evidence report by West and colleagues, Systems to Rate the Strength of Scientific Evidence.^85^

We also elected to limit our quality ratings to studies with at least moderate relevance because low-relevance studies were generally designed for purposes other than addressing planned cesarean delivery.

The only study eligible to be rated with an RCT form was the International Term Breech Trial (hereafter Breech Trial).^18,^ ^20,^ ^83^ Two of the criteria listed below (randomization approach, post-randomization exclusions) apply to the entire study; all others (masking, operational definitions and measures, loss to followup, and statistical analysis) apply to each article individually. We elected to rate each article in the Breech Trial individually because of significant variations in the article-specific criteria.

1 Randomization approach and implementation: This item judged whether the approach described a valid method of randomization, whether allocation concealment was achieved, and whether balance was documented across study groups.
  Approach: If the study assigned the groups in a manner inconsistent with true randomization methods, it had the potential to automatically receive a poor rating for this category and overall. If the study had merely stated that if “randomly assigned” the groups and either had no balance or did not report on balance, it would have received a poor rating. A study with no documentation of concealment or with inadequate concealment methods would have been rated poor if the study had poor balance of allocation or if balance was not documented. A study with potentially poor concealment would have been rated fair if they documented good balance.
2 Post-randomization exclusions: This item captured how many post-randomization exclusions were explicitly stated.
  Approach: In typical randomized trials, intention-to-treat analysis is expected. Any exclusions after randomization would have been considered inappropriate and would have led to a rating of poor.
3 Masking: This item was relevant only to outcome assessors.
  Approach: If the outcome assessors were adequately masked within the possibilities of the study design, we rated the category as good. If there was a mix of masking among the outcomes, we rated the category as fair. If masking was not done at all and not attempted, we rated the category as poor.
4 Operational definitions and measurements: This item judged the quality of the operational definitions of the outcomes (i.e., were they adequately described) and whether they were adequately collected (i.e., was the method sufficient and appropriate).
  Approach: We rated this category on the basis of an average across all outcomes for each timepoint and the ability to define and measure them. Good definitions and measurement include the following: validated questionnaires, detailed time points in question, details about what was asked of the patient, medical chart abstractions, and clinical examination or assessment. Failure to use such methods resulted in a rating in the fair-to-poor range, depending on how the article collected the information.
5 Loss to followup: This item collected percentages of followup at every time point in the study at which data were collected; we used it to determine if followup was adequate.
  Approach: In general, we considered followup greater than or equal to 90 percent in the short term and 80 percent in the long term to be good.
6 Statistical analysis: This factor included whether the investigators conducted the study in an appropriate manner and took the effect of multiple comparisons into account. This item also reviewed the study's use of multivariate statistical techniques and/or participant restriction or stratification to control for confounding.
  Approach: We rated this category on the basis of an average across all outcomes for each time point. Articles that reported appropriate statistical tests, point estimates, tests for homogeneity, stratification, and confidence intervals were rated as good. Articles that reported P-values alone were rated as fair, and articles that did not report statistical analysis were rated as poor.

Two article abstractors independently rated each article on each of the categories as indicated by the quality assessment form. We reconciled differences by consensus, giving each item equal weight. Specifically, articles that received good ratings on all categories would have been eligible to be rated as good studies overall. None of the three articles received a good rating. If an article received one or two fair or poor ratings, or the equivalent of a deficiency, it was rated as an overall fair-quality article. The original article from the Term Breech Trial, published in 2000, received a quality rating of fair.^20^ Articles with three or more fair ratings or a poor randomization design or implementation with a fatal flaw were rated as a poor-quality article. The two follow-up articles from the Breech Trial, published in 2002^18^ and 2004^83^ respectively, received a quality rating of poor.

We used the following criteria to rate the quality of nonrandomized observational studies:

1 Study design: Given the difficulties of identifying planned cesarean delivery retrospectively, we assigned prospective studies a higher score.
  Approach: To receive a rating of fair for this component of study design, we required a study to be prospective.
2 Study population: We sought documentation in the publication of the degree to which the study population was representative of women with uncomplicated spontaneous vaginal births in the study facilities or the broader population sampled.
  Approach: To receive a rating of good for this component of study design and conduct, we required a study to describe clearly (1) the base population from which cohort participants were sought, (2) the number of women in that base population (a denominator), and (3) the proportion of eligible women who were ultimately enrolled in the cohort.
  Studies with all three items were rated as good; studies lacking one item were classified as fair; and studies lacking more than one item were rated as poor.
3 Comparability of subjects. For cohort studies, we sought five tiers of documentation showing that the study had (1) specific inclusion/exclusion criteria for all groups, (2) applied criteria equally to all groups, (3) comparable study groups at baseline with reference to variables not unique to mode of delivery, (4) study groups comparable to nonparticipants with regard to confounding factors, and (5) study groups comparable with regard to followup.
  In addition, for case-control studies, we sought documentation on whether the study had (1) explicit case definition, (2) case ascertainment not influenced by exposure status, and (3) controls similar to cases except that they did not have the condition of interest and did have an equal opportunity for exposure.
  Approach: We rated a cohort study as having good comparability of subjects if at least four of five elements were present. We rated studies as having fair comparability if two or three elements were present. Studies with fewer than two elements were rated as poor. We required case-control studies to have all three elements of the case-control rating to rate a good for the overall category. We rated case-control studies that were missing one element for the case-control rating as fair and those missing two or more elements rated as poor.
4 Statistical analysis: We sought documentation on whether the study reported on the following aspects of statistical analysis: (1) appropriate statistical tests; (2) modeling and multivariate techniques or multiple comparisons; (3) power calculations and achieved sample size; (4) assessment of confounding by bivariate analysis, stratified analysis, or multivariable modeling; (5) reporting of adjusted estimates for main effects that took into account identified confounding or modifying factors (stratified or separate analyses were acceptable for simple constructs); and (6) presentation of adjusted results with a measure of statistical precision such as a confidence interval or P-value.
  Approach: We assigned a rating of good for the category of statistical analysis if studies provided at least five of the six elements above. We assigned a rating of fair if studies reported on three or four elements and a rating of poor if studies reported on fewer than three elements.
5 Result and loss to followup: For all studies, we sought documentation on whether the study reported a measure of effect for outcomes and provided an appropriate measure of precision. In addition, for panel studies, we sought documentation of two follow-up measures: (1) analysis of how respondents differed from nonrespondents if loss exceeded 20 percent, and (2) if absolute loss to followup exceeded 25 percent.
  Approach: For studies with cross-sectional measures, we assigned a rating of fair if the study reported a measure of effect with an appropriate measure of precision. Studies without a measure of effect were rated poor. Panel studies needed to have an absolute loss to followup at or below 25 percent. If the differential loss to followup from panel studies exceeded 20 percent, the investigators needed to report on bias from followup to receive a good rating. We rated a study as poor for this component if it had more than 25 percent loss to followup or more than 20 percent loss without comparison for response bias.

For categories 1 and 5 above, studies could receive a maximum rating of fair. For categories 2, 3, and 4, studies could receive a maximum rating of good. We summarized the ratings across all five categories to assign an overall rating as follows:

- good, if the study received a fair on both categories with a maximum of fair rating and good on all three categories with a maximum rating of good;
- fair, if the study received three to five fair scores with fewer than two good scores; or
- poor, if the study received two or fewer fair or good scores.

Grading the strength of available evidence. Our scheme follows the criteria applied by West et al.^85^ That system included three domains: quality of the research, quantity of studies (including number of studies and adequacy of the sample size), and consistency of findings. Two senior staff members assigned grades by consensus.

We graded the body of literature and present our findings in Chapter 4. The possible grades in our scheme are as follows:

I Strong: The evidence is from studies of strong design; results are both clinically important and consistent with minor exceptions at most; results are free from serious doubts about generalizability, bias, or flaws in research design. Studies with negative results have sufficiently large samples to have adequate statistical power.
II Moderate: The evidence is from studies of strong design, but some uncertainty remains because of inconsistencies or concern about generalizability, bias, research design flaws, or adequate sample size. Alternatively, the evidence is consistent but derives from studies of weaker design.
III Weak: The evidence is from a limited number of studies of weaker design. Studies with strong design either have not been done or are inconclusive.
IV No evidence: No published literature.

## External Peer Review

As is customary for all evidence reports and systematic reviews done for the Agency for Healthcare Research and Quality (AHRQ), the RTI-UNC EPC requested review of this report from a wide array of individual outside experts in the field, including our TEP, and from relevant professional societies and public organizations. AHRQ also requested review from its own staff and appropriate federal agencies. We initially asked 33 individuals or organizations about their interest and availability for peer review. Ultimately, we sent 18 invitations for peer review: to 5 TEP members, 6 relevant organizations, and 7 individual experts. Reviewers included clinicians (e.g., obstetrics, urogynecology, family practice, pediatrics), representatives of professional societies and advocacy groups, and potential users of the report.

We charged peer reviewers with commenting on the content, structure, and format of the evidence report, providing additional relevant citations, and pointing out issues related to how we had conceptualized and defined the topic and key questions. We also asked them to complete a peer review checklist. We received 15 responses in addition to comments from AHRQ staff. The individuals listed in Appendix E gave us permission to acknowledge their review of the draft. We compiled all comments and addressed each one individually, revising the text as appropriate.