# Introduction

## Context for Systematic Evidence Review of Cesarean Delivery on Maternal Request

The National Institutes of Health (NIH) Office of Medical Applications of Research (OMAR) reviews and evaluates clinically relevant NIH research program information and serves to promote the effective transfer of this information to the health care community. OMAR accomplishes this objective through its Consensus Development Program, which includes major Consensus Development conferences and State-of-the-Science conferences (SOS, when there is less definitive evidence available). OMAR, given the wide recognition of the limited literature available to guide clinical practice of cesarean delivery on maternal request (CDMR), planned an SOS Conference for March 2006. As background, OMAR commissioned this systematic review through the Agency for Healthcare Research and Quality (AHRQ) as a means of summarizing the available literature, framing the discussions regarding benefits and harms, and highlighting the limitations of the entire evidence base.

For the purposes of this review, cesarean delivery on maternal request is defined as a cesarean delivery for a singleton pregnancy, on maternal request, at term, and in the absence of any maternal or fetal indication for cesarean delivery. The panel chair of the SOS Conference, and a panel of independent technical experts (TEP) recognized that the available literature does not explicitly define CDMR as a specific study group to allow for comparison with other planned routes of delivery. Given this lack of evidence on CDMR per se, the TEP and SOS conference panel chair requested that we include proxies for CDMR such as cesarean deliveries for breech presentation.

We recognize that the ideal comparison groups to address the potential benefits and harms of CDMR would be planned vaginal delivery vs. planned CDMR in a low-risk population. We also note that planned vaginal delivery does not always result in spontaneous labor followed by spontaneous vaginal delivery.

The ideal evidence, therefore, demands a comparison of intent: planned vaginal delivery compared with planned CDMR rather than the comparison of actual delivery routes such as spontaneous vaginal delivery compared with unlabored cesarean. Such a comparison, based on intent to treat, is critical to assess the purported benefits of CDMR in reducing the risk of pelvic floor disorders (urinary incontinence, pelvic organ prolapse^*^ [loss of pelvic support], anal incontinence) because it is unclear whether or to what extent pelvic floor damage is caused by pregnancy itself, the first stage of labor [regular contractions to full cervical dilatation], or the second stage of labor [full dilatation to delivery—pushing phase]).

* Pelvic organ prolapse describes a group of conditions when one or more of the organs in the pelvis (the bladder, uterus, small intestines or rectum) fall into the vagina or through the vagina outside the body. Different terms describing prolapse include “cystocele” or “dropped bladder”; “uterine prolapse” or “dropped uterus”; “rectocele” or “enterocele.”^130^

In the absence of such high-quality evidence, we compiled a summary of the best available literature, using proxies for CDMR, frequently relying on studies that define groups by actual route of delivery and not planned route of delivery. Studies comparing actual and not planned route of delivery may provide inaccurate estimates of benefits and harms by reporting only outcomes of a limited group. For instance, a comparison of spontaneous vaginal delivery with unlabored cesarean may overestimate the risk of third-degree lacerations in the planned vaginal delivery group by not accounting for the group of women who ultimately underwent a cesarean delivery after attempting a vaginal delivery. Similarly, such a comparison would overestimate the risk of wound infection in the planned cesarean delivery group by not accounting for the higher rate of wound infection in women who ultimately underwent a cesarean delivery after attempting a vaginal delivery.

In addition, comparing actual routes of delivery rather than planned routes of delivery yields an inadequate assessment of potential confounders that, by definition, may influence both the route of delivery and the maternal or neonatal outcomes of interest. For instance, prolonged fetal bradycardia (fetal distress) can influence the need for an emergency delivery by cesarean, vacuum, or forceps and can also negatively affect neonatal outcomes. Studies that examine actual routes of delivery typically fail to account for such confounders.

To clarify the nature of these complex pathways and to highlight the potential confounders inherent in these comparisons, we present a framework of possible pathways for primiparous women with singleton pregnancies at term (see Figure 1). The pathways begin with planned routes of delivery, describe common labor events and potential confounders, and ultimately lead to various actual routes of delivery. As noted already, available studies often include comparison groups of actual routes of delivery for primiparous women with singleton pregnancies at term.

Figure 1. Possible pathways for planned vaginal and planned cesarean deliveries

On the left of Figure 1, we list the range of planned routes of delivery before labor. These include planned vaginal delivery and planned cesarean delivery for fetal indications, maternal indications, or upon maternal request. Given the lack of evidence on CDMR, planned cesarean for maternal indications or planned cesarean for fetal indications serve as proxies for CDMR, accounting for potential confounding effects when possible. For example, we consider cesarean delivery for breech as a proxy for CDMR for maternal outcomes. However, we do not consider this group as an appropriate proxy when assessing neonatal outcomes, because underlying pathology may result in both breech presentation and poor neonatal outcomes. (A later section of this chapter presents a note on terminology and glossary dealing further with the variable language for this topic.)

The middle section of Figure 1 includes labor events in either the first or second stage of labor that could necessitate a particular route of delivery and influence outcomes. These involve circumstances such as significant and prolonged fetal bradycardia (decrease in fetal heart rate), meconium-stained amniotic fluid (amniotic fluid containing material from fetal bowel movement), arrest of labor (slow or absent progress during the active phase of labor), cord prolapse (when the umbilical cord falls into the vagina prior to delivery), and placental abruption (placental detachment from the wall of the uterus). Generally, studies do not control for these potential confounders.

On the right of Figure 1, we show actual routes of delivery. In our review, most studies compare outcomes among various actual routes of delivery. As noted above, the ideal comparison would be between various planned routes of delivery. We attempt to describe such comparisons when available.

Our pathway for describing various routes of delivery for primiparous women with singleton pregnancies at term is not meant to represent a comprehensive flowchart of the multitude of prelabor and intrapartum events that may occur and that may alter the planned course of delivery. For instance, we do not describe planned vaginal delivery for either maternal or fetal indications (or both). However, we do include pathways for cesarean delivery for neonatal and maternal indications because these serve as the only available proxies for CDMR.

Significant advances in operative techniques, anesthesia, availability of antibiotics, and neonatal care over the past several decades have resulted in a decline in maternal and neonatal mortality.^1^ For this reason and in consultation with our TEP, AHRQ, and the SOS Conference panel chair, we limited our searches to articles published in or after 1990.

The remainder of this chapter describes the clinical and epidemiological issues related to CDMR, describes the four key questions (KQs) addressed by our systematic review, and presents an analytical framework for approaching the KQs.

## Clinical and Epidemiological Issues

The Centers for Disease Control and Prevention (CDC) reported that 29.1 percent of all births in the United States resulted from cesarean deliveries in 2004, an increase of 40 percent from 1996 and the highest percentage ever reported in the United States (see Figure 2).^2^ After declines between 1989 and 1996, the total cesarean rate and the primary cesarean rate (i.e., percentage of cesareans among women with no previous cesarean delivery, which was 20.6 percent in 2004) have increased each year.^2^

Figure 2. Total and primary cesarean rate and vaginal birth after previous cesarean (VBAC) rate — United States, 1989-2004

Among women with previous cesarean deliveries, the rate of vaginal birth after previous cesarean (VBAC) has dropped over time; the likelihood that subsequent deliveries would be cesarean was approximately 91 percent in 2004. Recent analysis from the Healthcare Cost and Utilization Project Nationwide Inpatient Sample suggests that “elective primary cesarean deliveries,” defined as a procedure that occurred before labor and without a previous history of cesarean delivery, rose from 19.7 percent of all cesarean deliveries in 1994 to 28.3 percent in 2001, an increase of approximately 43.6 percent.^3^ This statistic includes cesarean deliveries performed for malpresentation, antepartum bleeding, herpes, severe hypertension, uterine scar, multiple gestation, macrosomia (excessive weight or size of the infant, relative to gestational age), unengaged head (fetal head not applied to cervix), “soft tissue condition,” other hypertension, preterm, fetal anomaly, and unspecified indications; the contribution of CDMR to this statistic is unknown. The higher level of comfort that obstetricians feel with the risks associated with cesarean deliveries compared with those associated with vaginal deliveries may explain the rise in primary cesarean deliveries in part;^4^ physicians also may be justifying cesarean deliveries after a brief and “gentle” trial of labor.^5^

The topic of CDMR has drawn heightened interest and publicity. This attention can be attributed to the increased awareness that what happens in the delivery room has lifelong implications for both mother and child. The concerns associated with the increased rate of cesarean deliveries include the likelihood of higher risks from surgery, such as mortality, infection, anesthetic complications, hemorrhage, need for blood transfusions, and neonatal respiratory distress.

One purported benefit of CDMR is protection against pelvic floor disorders such as urinary incontinence, pelvic organ prolapse, and anal incontinence. Substantial controversy exists regarding appropriate clinical practice and whether CDMR should be made more widely available, in part to take advantage of this possible benefit and also to allow ease of scheduling the delivery for patients and providers. A recent editorial in the American College of Obstetricians and Gynecologists (ACOG) Clinical Review strongly suggested that CDMR be made more widely available to women.^1^ This recommendation was directed specifically toward nulliparous women or those who have undergone pelvic reconstructive surgery. Conversely, organizations such as the International Federation of Gynecology and Obstetrics (FIGO) support vaginal birth and believe that the practice of CDMR lacks ethical justification.^6^ However, the ACOG Ethics Committee determined that the physician is ethically justified in performing a CDMR if he or she believes that it promotes the overall health and welfare of the woman and her fetus but is equally justified in refusing to perform one if the physician believes it to be detrimental to the woman and her fetus.^7^

Significant variability associated with obstetrical practice and labor management makes it difficult to quantify the risk of CDMR. Given these uncertainties, no clear evidence guides informed decisionmaking regarding CDMR. As women's life expectancy has increased to 80.1 years of age over the past several decades,^8^ and as women remain active well into their postmenopausal years, attention to the antecedents of long-term maternal health outcomes is increasingly important.

## Key Questions and Analytic Framework

Table 1 presents the final key questions posed by AHRQ on behalf of OMAR. Figure 3 depicts the analytic framework we used to address the four key questions, given the flowchart for the various planned vaginal and planned cesarean pathways (in Figure 1).

Table 1 Key Questions posed by AHRQ on behalf of OMAR

Key Questions
1. What is the trend and incidence of cesarean delivery over time in the United States and in other countries?
a. What is the contribution of primary pre-labor cesarean deliveries?
b. Of the primary pre-labor cesarean deliveries what is the contribution of cesarean delivery on maternal request, for medical indications, and for malpresentation?
2. What are the short-term (under one year) and long-term benefits and harms to mother and baby associated with cesarean by request versus attempted vaginal delivery?
Maternal
Maternal outcomes—short term | Maternal outcomes—long term
1. Mortality* | 1. Urinary function*
2. Infection* | 2. Anorectal function*
3. Anesthesia* | 3. Pelvic organ prolapse*
4. Hemorrhage/blood transfusion* | 4. Sexual function*
5. Hysterectomy* | 5. Endometriosis
6. Thromboembolism | 6. Pelvic pain
7. Surgical complications | 7. Future fertility
8. Unplanned ICU admission | 8. Subsequent ectopic pregnancies
9. Wound breakdown | 9. Subsequent uterine rupture*
10. Breastfeeding | 10. Subsequent placental implantation issues*
11. Pain (labor and postoperative) | 11. Subsequent stillbirth*
12. Psychological | 12. Psychological
13. Readmission to hospital | 13. Subsequent surgery
14. Maternal length of stay | 14. Fistulae
15. Maternal recovery
Fetal/Neonatal
Fetal/Neonatal outcomes—short term | Neonatal outcomes—long term
1. Fetal mortality* | 1. Bonding and early behavioral issues
2. Neonatal mortality* | 2. Long-term development outcome
3. Unexpected (iatrogenic) prematurity*
4. Respiratory distress syndrome*
5. Metabolic complications
6. Transition issues
7. Transient tachypnea of the newborn*
8. Persistent pulmonary hypertension of the newborn
9. Encephalopathy/asphyxia*
10. Cerebral accident and stroke
11. Unplanned NICU/special care nursery
12. Birth Injury
13. Brachial plexus injury*
14. Fractures
15. Lacerations
16. Infections
17. Length of stay
18. Breastfeeding
3. What factors influence benefits and harms?
a. Fetal gender
b. Fetal size
c. Parity
d. Socioeconomics
e. Race/ethnicity
f. Maternal BMI
g. Maternal medical conditions
h. Pregnancy dating
i. Type of labor (e.g. augmented)
j. Physician experience/specialty
k. Delivery volume/level of perinatal care
l. Time of day of delivery
4. What future research directions need to be considered to get evidence for making appropriate decisions regarding cesarean on request or attempted vaginal delivery?

* ndicates outcomes considered of higher priority by the Conference Planning Committee

Figure 3. Analytic framework for cesarean delivery on maternal request

Given the time and resources available for this systematic review, we focused on the maternal and neonatal outcomes of high priority to the SOS conference planning committee. The maternal short-term outcomes include mortality, infection, anesthetic complications, hemorrhage or blood transfusion, hysterectomy, thromboembolism, surgical complications, breastfeeding, postpartum pain, psychological outcomes, and length of stay. The long-term maternal outcomes include urinary incontinence, anorectal function, pelvic organ prolapse, sexual function, subsequent fertility issues, subsequent placenta previa, subsequent uterine rupture, and subsequent stillbirth.

The analytic framework and this review concentrate on outcomes associated with primiparous births. Such an approach excludes two important outcomes that are particularly relevant to a comprehensive assessment of short-term and long-term risks associated with CDMR: (1) placental implantation abnormalities (previa, accreta, and percreta) and (2) uterine rupture generally associated with a trial of labor after cesarean.

Because the rate of VBAC is decreasing, women who undergo a first cesarean are likely to deliver future children through a similar route. Although we do not fully understand the mechanism by which placenta previa occurs,^9^ studies indicate that the risks of placenta previa and similar placental implantation abnormalities increase with the number of cesarean deliveries.^10^–^12^

In consultation with the TEP and the SOS Conference panel chair, we determined that a comprehensive assessment of these two outcomes—placental implantation abnormalities and uterine rupture—was beyond the scope and resources allocated for this review. However, given the importance of these two outcomes and the likelihood that they may significantly affect short- and long-term maternal and neonatal morbidity and mortality associated with hemorrhage or prematurity, respectively, we updated recently completed and well-designed systematic evidence reviews on these topics.

Neonatal outcomes included in this systematic evidence review include fetal mortality, neonatal mortality, unexpected (iatrogenic) prematurity, respiratory morbidity including transient tachypnea, respiratory distress syndrome, and persistent pulmonary hypertension, transition, neonatal encephalopathy and asphyxia, intracranial hemorrhage, facial nerve injury, brachial plexus injury, fetal laceration, neonatal length of stay, and long-term issues.

In consultation with our TEP, AHRQ, and the SOS Conference panel chair, we determined that this systematic evidence review would not examine outcomes unique to vaginal delivery in the absence of a cesarean comparison group. The examination of outcomes and modifiers of vaginal deliveries in studies without cesarean comparison groups was outside the scope and resources allocated to this review.

The following sections describe our conceptual approach to addressing the four KQs in greater detail.

### KQ 1: Trend and Incidence of Cesarean Delivery

This question includes trend and incidence of cesarean delivery over time and covers the contribution of primary prelabor cesarean deliveries. KQ 1 further seeks to determine the contribution of CDMR and other cesareans for other indications such as repeat elective cesarean deliveries, unlabored cesareans for medical indications (maternal or neonatal), unlabored cesareans for malpresentation, and labored cesareans after a planned vaginal delivery (Figure 3). These groupings will be particularly relevant to both maternal and neonatal outcomes because short- and long-term risks may be associated with the degree of effort exerted to achieve a vaginal delivery.^13^

Despite the theoretical importance of these distinctions, obtaining accurate data on the rate of cesarean delivery truly on maternal request in the absence of maternal or neonatal indications is challenging. Determining the true prevalence of CDMR in this country is difficult because such deliveries are often coded with other indications, possibly reflecting insurance coverage issues.^4^ However, some evidence suggests that such deliveries do occur and possibly at an increasing rate.^5,^ ^14^

We queried other sources of data to answer this key question. These include CDC, National Vital and Health Statistics, the World Health Organization, and sources from other nations such as Statistics Canada, the Australian Department of Human Services, and the United Kingdom Department of Health.

We defined “developed countries” as the United States, Canada, the United Kingdom, Western Europe, Israel, Australia, New Zealand, and Japan. We also tracked citations from other countries, such as Brazil.

### KQ 2: Effect of Planned Route of Delivery on Outcomes

Several factors make interpretation of the available evidence challenging. We summarize them in the following section.

Comparison of planned routes of delivery (intent to treat). As explained above, the appropriate comparison is that of intent: planned vaginal delivery compared with planned CDMR. The majority of studies included in this systematic review report outcomes by actual route of delivery. A design centered on actual delivery route often allows investigators to distinguish between labored and unlabored cesarean deliveries. In studies limited to unlabored cesareans, women who present in labor before their scheduled date of delivery are, by definition, excluded. Excluding these women may overestimate potential benefits (e.g., reduction in pelvic floor disorders) and potential harms (e.g., neonatal respiratory morbidity) associated with CDMR because the studies then cannot account for any effect that labor has on outcomes of interest.^15^–^17^ Studies that include both labored and unlabored planned cesareans may have a rate of labor that exceeds the rate of labor expected for a population planning CDMR and may allow for a longer period of time in labor before cesarean delivery.

Appropriate proxies for CDMR. We expected high-quality data on CDMR per se to be limited because CDMR is rarely listed as an indication for a cesarean delivery Available studies include a wide range of indications for cesarean that are highly variable in their relevance to CDMR. Use of cesarean for breech or other malpresentations is currently the closest proxy for CDMR. However, studies of cesarean deliveries for breech were designed with neonatal outcomes as primary endpoints; therefore, they may be limited in their ability to serve as proxies for CDMR for maternal outcomes. For instance, the International Term Breech trial (hereafter Breech Trial) allowed patients who presented in labor to be randomized to a cesarean delivery^18^ without adjusting for the length of the labor before cesarean or the length of time the membranes had been ruptured. As indicated above, the ideal comparison would involve intent and compare planned vaginal with planned CDMR. Thus, any protocol for CDMR would have some women going into labor before their planned cesarean; data from such deliveries ought to be analyzed as part of the planned CDMR group. However, the extent to which cesarean for breech serves as an accurate surrogate for CDMR is unclear because of uncertainty as to whether the time period between presentation in labor and cesarean delivery for breech is similar to that of CDMR. Issues such as prolonged rupture of membranes before the decision to perform a cesarean may increase the risk of other complications, such as maternal and neonatal infections and length of hospital stay.

Another major limitation to the use of breech as a proxy for CDMR is that when comparing study groups based on intent to treat, the risk of requiring a cesarean in the planned vaginal delivery group is likely to be significantly higher than if the fetus were vertex (head first).

Changing practice patterns. Practice patterns have changed considerably for both cesarean and vaginal deliveries over the past two decades. Historically, quantifying the risks and benefits of vaginal and cesarean births has been difficult, as the data on the risks associated with cesarean were based on older studies when cesarean deliveries were routinely performed under general anesthesia, after prolonged labor, and without the benefit of prophylactic antibiotics and thromboprophylaxis. Such surgical procedures are not comparable to CDMR under current standard practices. The absolute risks associated with a planned CDMR are likely to be lower in today's environment than they were previously,^19^–^23^ and they are dropping.^24^ Similarly, clinical management of planned vaginal delivery has also been improving, as in the declining use of episiotomy.^25,^ ^26^

The TEP and the SOS Conference panel chair decided to exclude studies published before 1990 to focus the systematic review on studies with practice patterns similar to contemporary norms. However, the studies we examine in this review do not necessarily include “best practices” for either vaginal or cesarean routes of delivery and demonstrate variable practice patterns among providers. For instance, studies generally do not clarify whether prophylactic antibiotics were administered for cesarean; this step, of course, can affect rates of maternal infection. Similarly, studies of vaginal delivery may reflect overuse of episiotomy, inappropriate thresholds for performing cesarean delivery, and inadequate management of labor. Therefore, a comparison of planned vaginal and planned cesarean ought to include the best clinical practice patterns for each of these intended routes of delivery. In the absence of information on the extent to which studies deviate from ideal practice patterns, how the balance of harms and benefits may shift in an ideal practice environment remains unclear.

Confounders. As noted earlier, ideal comparisons include planned vaginal delivery vs. planned cesarean delivery. The comparison of actual routes of delivery may result in inadequate assessment of confounders that influence both route of delivery and maternal or neonatal outcomes. For instance, confounders such as multiple gestations, placenta previa, and polyhydramnios (excess amniotic fluid) may increase the likelihood of preterm labor and delivery, may influence the recommended route of delivery, and may also result in poor maternal and neonatal outcomes.

Statistical power. The consequences of a fundamental shift to higher rates of CDMR are profound. They should be examined in well-designed studies that are adequately powered to detect clinically meaningful differences. The available literature that we discuss generally has sample sizes lower than are necessary to achieve adequate power, especially for rare outcomes.

Appropriate timing of outcome measurements. Decisions made in the delivery room have lifelong implications for the mother and infant. Ideal studies require that outcomes be assessed at time periods appropriate for that particular end result of care. Studies of the association between parturition-related variables including routes of delivery and pelvic floor disorders (urinary incontinence, pelvic organ prolapse, anal incontinence, and sexual dysfunction) are often limited to the immediate postpartum period. Assessing whether the condition results in long-term impairment is difficult in these studies.

Long-term outcome studies, although relatively uncommon, are often retrospective in design; they draw associations between current pelvic floor complaints and previous obstetrical events, sometimes decades earlier. These studies are often unable to collect specific information regarding planned routes of delivery or even sufficient detail regarding actual routes of delivery. Therefore, they frequently are unable to control for many important confounders such as interval pregnancies and deliveries and other factors that have been implicated in the development of pelvic floor disorders, such as length of labor, use of vacuum or forceps, obesity, smoking, constipation or chronic straining, or previous reconstructive pelvic surgery.

Measurement of outcomes (comprehensiveness, severity, and utility). Ideally, a systematic review of the outcomes of planned route of delivery should provide a comprehensive assessment of outcomes, accounting for the severity of symptoms and the utility of various outcomes to patients. For instance, accurate measurement of neonatal respiratory morbidity should include the risks of all forms of harm associated with planned route of delivery, including potentially higher risks of meconium aspiration in planned vaginal deliveries^27^ and potentially higher risks of transient tachypnea of the newborn and respiratory distress syndrome in planned cesarean deliveries.

The issue of severity rating is particularly important for pelvic floor outcomes such as urinary incontinence, pelvic organ prolapse, or anal incontinence. An undifferentiated measure of urinary incontinence that does not account for severity would mask the considerable difference in quality of life between a small amount of leakage that occurs rarely and severe, daily urinary leakage. Similarly, neonatal outcomes such as respiratory morbidity need to be categorized and analyzed by degree of severity. For instance, transient tachypnea of the newborn (TTN) and respiratory distress syndrome (RDS) represent extremes of severity; investigators should not group them into a single measure of respiratory morbidity, because doing so may obscure meaningful differences between groups.

Factoring in both severity and utility when assessing the overall benefit and harm of CDMR is critically important. A woman considering a planned route of cesarean delivery needs to assess comprehensively both short- and long-term risks, to both herself and her infant, and in both the current pregnancy and future pregnancies. Currently, clinicians and others have little or no way to judge the “priority” of a range of possible outcomes. For instance, urinary incontinence needs to be described in a manner that relates both its occurrence and severity and that provides a utility weighting relative to other potential outcomes such as wound infection. Similarly, in assessing overall harms and benefits to the neonate, the potentially higher risk of neonatal respiratory morbidity (TTN and RDS) associated with a planned CDMR needs to be weighed against the potential reduction in the rate of other outcomes such as stillbirths after 39 weeks, intrapartum deaths, and shoulder dystocias (emergency occurring when infant's shoulder gets “stuck”) associated with a planned vaginal delivery.

### KQ 3: Magnitude of Benefits and Harms

As suggested by our analytic framework (Figure 3), the choice of CDMR or a planned vaginal delivery, as well as the rates and severity of subsequent maternal and fetal or neonatal benefits and harms, may be influenced by several maternal, fetal, provider, and health care system characteristics. Given that few studies control for or assess the effect of such factors on maternal and fetal outcomes, we acknowledge the challenges of measuring the magnitude of these factors on maternal and fetal or neonatal outcomes. As in KQ 2, we stratified the analysis into unlabored and labored cesarean deliveries as well as planned vaginal deliveries.

### KQ 4: Future Research

We anticipate that even after this comprehensive systematic review has been discussed at the SOS conference and published, appreciable uncertainty will remain about the risks associated with CDMR. Suggestions to address these limitations of the literature, put forward in our discussion of KQ 4, will guide the development and direction of future research.

Understanding some of the gaps in the literature at this point may help readers interpret our analyses and findings for KQs 1, 2, and 3. Especially important are problems related to the characterization of CDMR and other modes of delivery that typically serve as proxies for CDMR. These include cesareans for breech and other ambiguous categorizations, which may be called “elective,” “planned,” “nonemergency,” “unlabored,” and “scheduled” cesareans. This variability in language is not trivial, and readers of this evidence report are cautioned against assuming that various research teams in fact mean the same thing by the same term or that use of different terms accurately depicts different situations.

In addition, we have assessed maternal and neonatal outcomes and weighted them based on the level of relevance to CDMR, the quality of individual study, and the overall strength of evidence for each particular outcome measure. In taking this approach, we have identified several outcomes that require substantial additional research. The analytic framework provides the infrastructure for designing future studies by highlighting particularly relevant comparison groups. Although a comprehensive assessment that balances outcomes based on their relative rates and utilities or disutilities is the ideal, this goal is probably still unattainable.

### A Note on Terminology

The purpose of this systematic review is to address CDMR, but the paucity of literature on the topic requires the use of proxies. As noted above, studies in this review use nonstandardized terms such as “elective,” “scheduled,” “planned,” “labored,” “unlabored,” “urgent,” “emergent,” and “emergency” cesarean deliveries. Table 2 provides a glossary of these general terms as they are commonly used. Not all studies use these exact definitions; in fact, they may use definitions that differ significantly from those employed in other studies. For instance, the term “primary elective” cesarean is widely interpreted as referring to a woman's first cesarean delivery, planned for a wide range of maternal and fetal indications and generally distinguished from emergency cesarean delivery and labored cesarean delivery after planned vaginal delivery. However, one study included 9 percent of women undergoing a repeat cesarean in their “primary elective” cesarean group. The authors of this study defined the term “primary elective” cesarean as a “planned operation in which the patient had been admitted to the hospital at least 8 hours before the cesarean without symptoms of labor,”^28^ ^p. 2^ allowing for inclusion of repeat cesareans.

Table 2 Glossary of terms

Cesarean Delivery
Cesarean delivery on maternal request (CDMR): A cesarean delivery for a singleton pregnancy, on maternal request, at term, and in the absence of any maternal or fetal indication for cesarean delivery.
Elective cesarean delivery: Generally includes a planned cesarean for a wide range of maternal and fetal indications, generally distinguished from emergency cesarean delivery and labored cesarean delivery after planned vaginal delivery. This category includes CDMR. This category may also include patients that go into labor prior to their scheduled delivery date.
Emergency cesarean delivery: A cesarean delivery that is performed expeditiously, in which delay may result in significant maternal or neonatal harm, sometimes referred to as emergent.
Labored cesarean delivery: A cesarean delivery that is performed after the onset of labor. This category could include planned and unplanned cesarean deliveries.
Planned cesarean delivery: A subset of elective cesarean delivery where the intent to deliver by cesarean is determined prior to labor. Of note, this category includes all deliveries resulting from a decision to pursue an intended cesarean delivery, including patients that present in active labor before their scheduled delivery date and are allowed to deliver vaginally either spontaneously or with vacuum or forceps assistance. Use of this category facilitates comparison based on intended routes of delivery.
Primary cesarean delivery: A cesarean delivery in a woman without a prior history of cesarean.
Repeat cesarean delivery: A cesarean delivery in a woman with a prior history of cesarean delivery.
Scheduled cesarean delivery: A term used synonymously with planned cesarean delivery.
Unlabored cesarean delivery: A cesarean delivery performed before the onset of labor. This category may include planned and unplanned cesarean deliveries as well as emergency cesarean deliveries in the absence of labor.
Unplanned cesarean delivery: A cesarean delivery that occurs in a woman who planned a vaginal delivery but who required a cesarean delivery for either a maternal or neonatal indication that arose prior to or during labor. This category includes emergency cesareans whose indications became evident prior to or during labor.
Urgent cesarean delivery: A cesarean delivery in which surgery needed to be performed in a timely manner but not as an immediate emergency delivery.
Vaginal Delivery
Assisted vaginal delivery: A vaginal delivery that requires the use of forceps, vacuum, or both.
Planned vaginal delivery: A delivery resulting from a decision to pursue an intended vaginal delivery. This category includes spontaneous vaginal delivery, vacuum-assisted vaginal delivery, forceps-assisted vaginal delivery, and unplanned cesarean deliveries. Use of this category facilitates comparison based on intended routes of delivery.
Spontaneous vaginal delivery: A vaginal delivery that occurs without the assistance of forceps or vacuum. This category may include both spontaneous onset of labor and induced labor.

In discussing studies, we clearly specify each study's definition with respect to medical indications for cesarean and laboring status. In recognition of the variation across definitions, we elected to use the term that the authors used, denoting such terms by using quotation marks, rather than try to impose a single, overarching term such as elective cesarean delivery or CDMR.

## Organization of This Evidence Report

Chapter 2 describes our methods, including our search strategies and inclusion/exclusion criteria; we also document our approach to rating the relevance of each study to CDMR, grading the quality of articles, and rating the strength of evidence. In Chapter 3, we present the results of our literature search and synthesis of retained articles for three issues (KQs 1, 2, and 3). Chapter 4 further discusses the findings, presents our conclusions, and offers recommendations for future research (KQ 4). References follow Chapter 4. Appendixes^*^ include a detailed description of our search strings (Appendix A), abstraction and quality-rating forms (Appendix B), detailed evidence tables (Appendix C), list of excluded studies (D), and acknowledgments (Appendix E).

* Appendixes and Evidence Tables for this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/cesarean/cesarreq.pdf

## Technical Expert Panel (TEP)

We identified seven technical experts in the field of obstetrics to provide assistance throughout the project; they included specialists in maternal fetal medicine, general obstetrics and gynecology, urogynecology, family medicine, pediatrics, and nurse-midwifery. The TEP (Appendix D) was expected to contribute to AHRQ's broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products. Thus, the TEP was both an additional resource and a sounding board during the project.

To ensure robust, scientifically relevant work, we called on the TEP to provide reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEP members participated in conference calls and discussions through e-mail to

- refine the analytic framework and key questions at the beginning of the project;
- discuss the preliminary assessment of the literature, including inclusion/exclusion criteria; and
- provide input on the information and categories included in evidence tables.

Because of their extensive knowledge of the literature, which includes numerous articles authored by TEP members themselves, and their active involvement in professional societies and as practitioners in the field, we also asked TEP members to participate in the external peer review of the draft report. TEP proceedings included the panel chair of OMAR's SOS Conference.