# Appendix E: Acknowledgments

This study was supported by Contract 290-02-0016 from the Agency for Healthcare Research and Quality (AHRQ), Task No. 5. We acknowledge the continuing support of Kenneth Fink, JD, MA, Director of the AHRQ Evidence-Based Practice Center (EPC) Program, and Susan Meikle, MD, MSPH, the AHRQ Task Order Officer for this project. We would also like to extend our appreciation to Lata S. Nerurkar, Ph.D., Barnett S. Kramer, M.D., M.P.H., and Susan Rossi, Ph.D., M.P.H from the Office of Medical Applications of Research.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina (UNC). From UNC, we thank EPC Co-Director, Timothy S. Carey, MD, MPH; EPC Literature Search Specialist, Laura Morgan, UNC Research Assistant, B. Lynn Whitener, PhD., and Shauna Hay, BS, UNC Research Assistant. We also express our gratitude to Loraine Monroe, EPC word processing specialist and Carol Offen, BA, Editor, at RTI International.

## Technical Expert Panel

We also extend our appreciation to the members of our Technical Expert Panel (TEP), who provided advice and input during our research process. The RTI-UNC EPC team solicited the views of TEP members from the beginning of the project. TEP members also provided insights into and reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEP members participated in refining the analytic framework and key questions and discussing the preliminary assessment of the literature, including inclusion/exclusion criteria, and also provided input on the information and categories, including evidence tables. The TEP was both a substantive resource and a “sounding board” throughout the study. It was also the body from which expertise was formally sought at several junctions. TEP members are listed below:

- Leah Albers, CNM, DrPH, FACNM, FAAN^*^
  * Denotes that the TEP member was also a peer reviewer for the report.
- Professor
- University of New Mexico College of Nursing
- Albuquerque, NM

- Haywood Brown, MD^*^
- Chair
- Department of Obstetrics/Gynecology
- Duke University School of Medicine
- Durham, NC

- Linda Brubaker, MD^*^
- Professor of Obstetrics/Gynecology and Urology
- Loyola University
- Chicago, IL

- Jeffrey Ecker, MD^*^
- Director
- Obstetrical Clinical Research,
- Massachusetts General Hospital
- Boston, MA

- Valerie J. King, MD, MPH^*^
- Research Assistant Professor
- Department of Family Medicine
- Oregon Health & Science University
- Portland, OR

- Kenneth J. Leveno, MD
- Gillette Professor, Department of Obstetrics/Gynecology
- Vice-Chair for Maternal-Fetal Medicine
- The University of Texas Southwestern Medical Center
- Dallas, Texas

- Mary D'Alton, MD
- Chair
- Department of Obstetrics & Gynecology
- Columbia University Medical Center.
- New York, NY

- Marie McCormick, MD
- Professor of Pediatrics
- Harvard Medical School
- Cambridge, MA

## Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. External reviewers comprised clinicians, researchers, representatives of professional societies, and potential users of the report. We would also like to extend our appreciation to David Atkins, MD, and Susan Meikle, MD, MSPH from AHRQ for contributing peer review comments. Our peer review panel also includes four members of the TEP. Peer review was a separate duty for these individuals and not part of their commitment as TEP members. All are active professionals in the field. The peer reviewers were asked to provide comments on the content, structure, and format of the evidence report and to complete a checklist. The peer reviewers' comments and suggestions formed the basis of our revisions to the evidence report. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

- Melissa D. Avery, CNM, PhD, FACNM
- Associate Professor, Director, Nurse-Midwifery Program
- University of Minnesota,
- School of Nursing

- Deborah Campbell MD, FAAP
- Chairperson, Section on Perinatal Pediatrics
- American Academy of Pediatrics

- Mark Landon, M.D.
- Professor/ Division Director
- Department of Obstetrics and Gynecology
- Division of Maternal/ Fetal Medicine
- Ohio State University

- Elizabeth Cooper, CNM, EdD, FACNM
- Associate Professor of Obstetrics/Gynecology and Nursing
- University of Rochester Medical Center

- William Hueston, MD
- Chair, Department of Family Medicine; Professor
- Medical University of South Carolina

- Cheryl Iglesia, MD
- Director of Urogynecology and Reconstructive Pelvic Surgery
- Washington Hospital Center

- Brian Mercer, MD
- Director
- Department of Obstetrics and Gynecology
- MetroHealth Medical Center
- Case Western Reserve University

- Peggy A. Norton, MD
- Associate Professor and Division Chief of Urogynecology
- University of Utah Medical Center
- University Of Utah