# Appendix D: Listing of Excluded Studies

[underlined: Codesheet for Cesarean Reasons for Exclusion]

[underlined: Code] | [underlined: Meaning of Code]
BKGRD | Background
DA | Decision analysis
FTE3 | Not original research
FTE4 | Ineligible geographic location
FTE5 | Incorrect population of study participants
FTE6 | Does not address study questions
FTE7 | Ineligible study design
FTE8 | Sample size too small
FTE9 | Unabstractable
FTE10 | Could not acquire
FTE11 | Not relevant to previa update

## References

Prevalent urinary incontinence as a correlate of pregnancy, vaginal childbirth and obstetric techniques. J Wound Ostomy Continence Nurs 1999; 26(3):28A-9A. Notes: Urinary Incontinence Search; Journal Article AI FTE6
Rates of cesarean delivery—United States, 1993. MMWR Morb Mortal Wkly Rep 1995;44(15):303–7. Notes: HAND SEARCH AI FTE11
Abu-Heija AT, Jallad MF, Abukteish F. Maternal and perinatal outcome of pregnancies after the age of 45. J Obstet Gynaecol Res. 2000;26(1):27-30. Notes: PREVIA UPDATE. AI. FTE11. [pmid: 10761327].
Acien P. Breech presentation in Spain, 1992: a collaborative study. Eur J Obstet Gynecol Reprod Biol. 1995;62(1):19-24. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 7493702].
Al-Abdulhadi O, Biehl D, Ong B, Boker A. A comparison of spinal hyperbaric ropivacaine and hyperbaric bupivacaine for elective cesarean section. Can J Anesth. 2004;51(Suppl 1):A55. Notes: (39) CCT (42) Cochrane CCTR Search; Label: PBS Record: 10. AI. FTE6.
Albrechtsen S, Rasmussen S, Reigstad H, Markestad T, Irgens LM, Dalaker K. Evaluation of a protocol for selecting fetuses in breech presentation for vaginal delivery or cesarean section. Am J Obstet Gynecol. 1997;177(3):586-92. Notes: Comparison Studies Journal Article. AI. FTE5. FTE6. [pmid: 9322628].
Alcalay M, Hourvitz A, Reichman B, et al. Prelabour rupture of membranes at term: early induction of labour versus expectant management. Eur J Obstet Gynecol Reprod Biol. 1996;70(2):129-33. Notes: Neonate outcome study Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE6. [pmid: 9119091].
Allen J, Hippisley-Cox J, Pringle M, Groom L. Assisted delivery in the teenage population: the effect of inter-hospital variation, deprivation, and age. Int J Adolesc Med Health. 2003;15(4):341-7. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 14719416].
Amarin VN, Akasheh HF. Advanced maternal age and pregnancy outcome. East Mediterr Health J. 2001;7(45):646-51. Notes: PREVIA UPDATE. AI. FTE11. [pmid: 15332761].
Amoa AB, Klufio CA, Wat S, Kariwiga G, Mathias A. A retrospective survey of patients with one previous caesarean section delivered at the Port Moresby General Hospital: a comparative study of those delivered vaginally and those delivered by repeat caesarean section. P N G Med J. 1997;40(34):127-35. Notes: Outcomes Studies; Harms Search; KQ1 Search Journal Article. AI. FTE4. FTE6. [pmid: 10750409].
Amu O, Rajendran S, Bolaji I. Should doctors perform an elective caesarean section on request? Maternal choice alone should not determine method of delivery. Br Med J. 1998;317(7156):463-5. Notes: Harms Search; Journal Article. AI. FTE3. FTE4. FTE5. FTE6. FTE7. FTE8. BKGRD. [pmid: 9758469].
Ananth CV, Demissie K, Smulian JC, Vintzileos AM. Placenta previa in singleton and twin births in the United States, 1989 through 1998: a comparison of risk factor profiles and associated conditions. Am J Obstet Gynecol. 2003;188(1):275-81. Notes: PREVIA UPDATE. AI. FTE11. [pmid: 12548229].
Ananth CV, Smulian JC, Vintzileos AM. The association of placenta previa with history of cesarean delivery and abortion: a metaanalysis. Am J Obstet Gynecol. 1997;177(5):1071-8. Notes: Journal ArticleMeta-Analysis Placenta Previa Search. AI. FTE3. FTE6. [pmid: 9396896].
Ananth CV, Wilcox AJ, Savitz DA, Bowes WA jr, Luther ER. Effect of maternal age and parity on the risk of uteroplacental bleeding disorders in pregnancy. Obstet Gynecol. 1996;88(4 Pt 1):511-6. Notes: Journal Article Placenta Previa Search. AI. FTE6. DA. [pmid: 8841208].
Annibale DJ, Hulsey TC, Wagner CL, Southgate WM. Comparative neonatal morbidity of abdominal and vaginal deliveries after uncomplicated pregnancies. Arch Pediatr Adolesc Med. 1995;149(8):862-7. Notes: Harms Search; Journal Article. AI. FTE6. [pmid: 7633538].
Appleby J. Data briefing. Caesarean births. Health Serv J. 2001;111(5756):31. Notes: infant and c-section additions. AI. FTE9.
Armstrong CA, Harding S, Matthews T, Dickinson JE. Is placenta accreta catching up with us?. Aust N Z J Obstet Gynaecol. 2004;44(3):210-3. Notes: Journal Article Placenta Previa Search. AE. FTE12. [pmid: 15191444].
Arsiradam N, Maliti Z, Rocke D. Ropivacaine 7.5 mg/ml for epidural anesthesia in elective Cesarean section: a comparison with 5mg/ml bupivacaine. Anesth Analg. 1998;86(Suppl):S361. Notes: Cochrane CCTR Search; EMBASE Search; Label: PBS Record: 400. AI. FTE4. FTE6.
Avva R, Shah HR, Angtuaco TL. US case of the day. Placenta increta. Radiographics. 1999;19(4):1089-92. Notes: Case Reports Journal Article Placenta Previa Search. AI. FTE3. FTE6. [pmid: 10464813].
Bagnoli F, Bruchi S, Garosi G, Pecciarini L, Bracci R. Relationship between mode of delivery and neonatal calcium homeostasis. Eur J Pediatr. 1990;149(11):800-3. Notes: infant and c-section additions. AI. FTE6. BKGRD. [pmid: 2226557].
Bagratee JS, Moodley J, Kleinschmidt I, Zawilski W. A randomised controlled trial of antibiotic prophylaxis in elective caesarean delivery. Br J Obstet Gynaecol. 2001;108(2):143-8. Notes: RCT Search; Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE4.
Bahl R, Strachan B, Murphy DJ. Pelvic floor morbidity at 3 years after instrumental delivery and cesarean delivery in the second stage of labor and the impact of a subsequent delivery. Am J Obstet Gynecol. 2005;192(3):789-94. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 15746673].
Bahl R, Strachan BK. Mode of delivery in the next pregnancy in women who had a vaginal delivery in their first pregnancy. J Obstet Gynaecol. 2004;24(3):272-3. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. DA. [pmid: 15203624].
Bai SW, Lee HJ, Cho JS, Park YW, Kim SK, Park KH. Peripartum hysterectomy and associated factors. J Reprod Med. 2003;48(3):148-52. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 12698770].
Bailit JL, Love TE, Mercer B. Rising cesarean rates: are patients sicker?. Am J Obstet Gynecol. 2004;191(3):800-3. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 15467544].
Bais JM, van der Borden DM, Pel M, et al. Vaginal birth after caesarean section in a population with a low overall caesarean section rate. Eur J Obstet Gynecol Reprod Biol. 2001;96(2):158-62. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. [pmid: 11384799].
Bamigboye AA, Hofmeyr GJ. Non-closure of peritoneal surfaces at caesarean section—a systematic review. S Afr Med J. 2005;95(2):123-6. Notes: Outcomes Studies; Journal Article. AI. FTE3. FTE6. [pmid: 15751208].
Bashore RA, Phillips WH Jr. Brinkman CR3. A comparison of the morbidity of midforceps and cesarean delivery. Am J Obstet Gynecol. 1990;162(6):1428-34. discussion 1434–5. Notes: infant and c-section additions. AI. FTE6. [pmid: 2360575].
Bekku S, Mitsuda N, Ogita K, Suehara N, Fujimura M, Aono T. High incidence of respiratory distress syndrome (RDS) in infants born to mothers with placenta previa. J Matern Fetal Med. 2000;9(2):110-3. Notes: Harms Search; Journal Article. AE. FTE12. [pmid: 10902824].
Ben-Aroya Z, Hallak M, Segal D, Friger M, Katz M, Mazor M. Ripening of the uterine cervix in a post-cesarean parturient: prostaglandin E2 versus Foley catheter. J Matern Fetal Neonatal Med. 2002;12(1):42-5. Notes: Comparison Studies Clinical Trial Journal Article. AI. FTE6. [pmid: 12422908].
Berchuck A, Sokol RJ. Previous cesarean section, placenta increta, and uterine rupture in second-trimester abortion. Am J Obstet Gynecol. 1983;145(6):766-7. Notes: Case Reports; Journal Article Placenta Previa Search. AI. FTE3. FTE6. FTE7. FTE8. [pmid: 6829668].
Bewley S, Cockburn J. II. The unfacts of ‘request’ caesarean section. Br J Obstet Gynaecol 2002; 109 (6):597–605. Notes: Urinary Incontinence Search; Harms Search; KQ1 Search Comment Journal Article AI FTE3 FTE5 FTE6 FTE7 FTE8 BKGRD
Bhat SM, Hamdi IM, Bhat SK. Placenta previa in a referral hospital in Oman Saudi Med J. 2004;25(6):728-31. Notes: PREVIA UPDATE. AI. FTE11.
Blackwell SC, Hassan SS, Wolfe HM, Michaelson J, Berry SM, Sorokin Y. Vaginal birth after cesarean in the diabetic gravida. J Reprod Med. 2000;45(12):987-90. Notes: Comparison Studies Journal Article. AI. FTE6. [pmid: 11153259].
Blanchette H. Comparison of obstetric outcome of a primary-care access clinic staffed by certified nurse-midwives and a private practice group of obstetricians in the same community. Am J Obstet Gynecol. 1995;172(6):1864-8. discussion 1868–71. Notes: Comparison Studies Journal Article. AI. FTE6. [pmid: 7778645].
Blanchette H, Blanchette M, McCabe J, Vincent S. Is vaginal birth after cesarean safe? Experience at a community hospital. Am J Obstet Gynecol. 2001;184(7):1478-84. discussion 1484–7. Notes: Outcomes Studies; Journal Article. AI. FTE6. [pmid: 11408871].
Bollapragada SS, Edozien LC. Apparent absence of lochia after elective caesarean section. J Obstet Gynaecol. 2002;22(5):558. Notes: Harms Search; Case Reports Journal Article. AI. FTE3. FTE6. FTE7. FTE8. [pmid: 12521434].
Boyers SP, Gilbert WM. Elective repeat caesarean section versus trial of labour: the neonatologist's view. Lancet. 1998;351(9097):155. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE3. FTE7. BKGRD. [pmid: 9449865].
Brubaker L. Postpartum urinary incontinence. Br Med J. 2002;324(7348):1227-8. Notes: Urinary Incontinence Search; Comment Editorial. AI. FTE3. [pmid: 12028960]. [pmcid: 1123200].
Brubaker L. Vaginal delivery and the pelvic floor. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(6):363-4. Notes: Urinary Incontinence Search; Editorial. AI. FTE3. FTE4. FTE5. FTE6. FTE7. [pmid: 9891956].
Brueckner-Schmid B, Petzold I, Bruekner J. Rapacuronium for rapid sequence induction in elective cesarean section. Society for Obstetric Anesthesia and Perinatology 33rd Annual Meeting. Anesthesiology, 2001: A84. Notes: Cochrane CCTR Search; Label: PBS Record: 180 AI FTE6 FTE8
Brumfield CG, Hauth JC, Andrews WW. Puerperal infection after cesarean delivery: evaluation of a standardized protocol. Am J Obstet Gynecol. 2000;182(5):1147-51. Notes: HAND SEARCH. AI. FTE6. [pmid: 10819850].
Bryan H, Hawrylyshyn P, Hogg-Johnson S, et al. Perinatal factors associated with the respiratory distress syndrome. Am J Obstet Gynecol. 1990;162(2):476-81. Notes: infant and c-section additions. AI. FTE5. FTE6. [pmid: 2309834].
Buist R. Induction of labour: indications and obstetric outcomes in a tertiary referral hospital. N Z Med J. 1999;112(1091):251-3. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. [pmid: 10448982].
Bunin GR, Buckley JD, Boesel CP, Rorke LB, Meadows AT. Risk factors for astrocytic glioma and primitive neuroectodermal tumor of the brain in young children: a report from the Children's Cancer Group. Cancer Epidemiol Biomarkers Prev. 1994;3(3):197-204. Notes: infant and c-section additions. AI. FTE6. [pmid: 8019366].
Burnett M. Optional Caesarean: what do some Canadian physicians say?. J Obstet Gynaecol Can. 2002;24(3):219-20. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE3. FTE5. FTE6. BKGRD. [pmid: 12585246].
Busch FW, Hamdorf JM, Carroll CSSr, Magann EF, Morrison JC. Acute colonic pseudo-obstruction following cesarean delivery. J Miss State Med Assoc. 2004;45(11):323-6. Notes: infant and c-section additions. AI. FTE3. FTE6. [pmid: 15624628].
Busowski JD, Chez RA, Goldfain VM. The effect of a resident night team on cesarean delivery. Am J Perinatol. 1997;14(4):177-80. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. [pmid: 9259923].
Byrne B, Morrison JJ. Preterm birth. Clin Evid 2002; (7):1310–24. Notes: Neonate outcome study Journal Article Review AI FTE3
Camann WR, Loferski BL, Fanciullo GJ, Stone ML, Datta S. Does epidural administration of butorphanol offer any clinical advantage over the intravenous route? A double-blind, placebo-controlled trial. Anesthesiology. 1992;76(2):216-20. Notes: RCT Search; Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE8. [pmid: 1736698].
Cammu H, Martens G, Ruyssinck G, Amy JJ. Outcome after elective labor induction in nulliparous women: a matched cohort study. Am J Obstet Gynecol. 2002;186(2):240-4. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. [pmid: 11854642].
Carley ME, Turner RJ, Scott DE, Alexander JM. Obstetric history in women with surgically corrected adult urinary incontinence or pelvic organ prolapse. J Am Assoc Gynecol Laparosc. 1999;6(1):85-9. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 9971858].
Carlson B. Changing medical evidence brings shift in C-section stance. Manag Care. 2003;12(1):32-3. Notes: KQ1 Search Journal Article. AI. FTE3. FTE6. [pmid: 12575508].
Carroll CSSr, Magann EF, Chauhan SP, Klauser CK, Morrison JC. Vaginal birth after cesarean section versus elective repeat cesarean delivery: Weight-based outcomes. Am J Obstet Gynecol. 2003;188(6):1516-20. discussion 1520–2. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE6. [pmid: 12824987].
Celleno D, Capogna G, Emanuelli M, et al. Which induction drug for cesarean section? A comparison of thiopental sodium, propofol, and midazolam. J Clin Anesth. 1993;5(4):284-8. Notes: RCT Search; Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE6. FTE8. [pmid: 8373604].
Chaliha C, Digesu A, Hutchings A, Soligo M, Khullar V. Caesarean section is protective against stress urinary incontinence: an analysis of women with multiple deliveries. Br J Obstet Gynaecol. 2004;111(7):754-5. Notes: Urinary Incontinence Search; Outcomes Studies; Harms Search; Journal Article. AI. FTE8. BKGRD.
Chaliha C, Khullar V, Stanton SL, Monga A, Sultan AH. Urinary symptoms in pregnancy: are they useful for diagnosis?. Br J Obstet Gynaecol. 2002;109(10):1181-3. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6.
Chanrachakul B, Hamontri S, Herabutya Y. A randomized comparison of postcesarean pain between closure and nonclosure of peritoneum. Eur J Obstet Gynecol Reprod Biol. 2002;101(1):31-5. Notes: RCT Search; Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE4. FTE6. [pmid: 11803097].
Chattopadhyay SK, Kharif H, Sherbeeni MM. Placenta praevia and accreta after previous caesarean section. Eur J Obstet Gynecol Reprod Biol. 1993;52(3):151-6. Notes: Journal Article Placenta Previa Search. AI. FTE4. FTE6. [pmid: 8163028].
Chauhan SP, Magann EF, Bufin L, Carroll S, Morrison JC. Umbilical arterial pH < 7.00 in newborns delivered by nonelective cesarean delivery: risk factors and peripartum outcomes. Am J Perinatol. 2004;21(5):281-7. Notes: infant and c-section additions. AI. FTE6. FTE8. [pmid: 15232761].
Chazotte C, Cohen WR. Catastrophic complications of previous cesarean section. Am J Obstet Gynecol. 1990;163(3):738-42. Notes: Journal Article Placenta Previa Search. AI. FTE6. FTE8. DA. [pmid: 2403155].
Chelmow D, Andrew DE, Baker ER. Maternal cigarette smoking and placenta previa. Obstet Gynecol. 1996;87(5 Pt 1):703-6. Notes: Journal Article Placenta Previa Search. AI. FTE6. [pmid: 8677070].
Chen CH, Wang SY. Psychosocial outcomes of vaginal and cesarean births in Taiwanese primiparas. Res Nurs Health. 2002;25(6):452-8. Notes: Outcomes Studies; Journal Article. AI. FTE4. [pmid: 12424782].
Chen GD, Lin TL, Hu SW, Chen YC, Lin LY. Prevalence and correlation of urinary incontinence and overactive bladder in Taiwanese women. Neurourol Urodyn. 2003;22(2):109-17. Notes: Urinary Incontinence Search; Journal Article. AI. FTE4. FTE6. [pmid: 12579627].
Cheng CR, Su TH, Hung YC, Wang PT. A comparative study of the safety and efficacy of 0.5% levobupivacaine and 0.5% bupivacaine for epidural anesthesia in subjects undergoing elective caesarean section. Acta Anaesthesiol Sin. 2002;40(1):13-20. Notes: RCT Search; Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE4. FTE8. [pmid: 11989042].
Chou MM, MacKenzie IZ. A prospective, double-blind, randomized comparison of prophylactic intramyometrial 15-methyl prostaglandin F2 alpha, 125 micrograms, and intravenous oxytocin, 20 units, for the control of blood loss at elective cesarean section. Am J Obstet Gynecol. 1994;171(5):1356-60. Notes: Cochrane CCTR Search; EMBASE Search; Harms Search; RCT Search; Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE6. FTE8. [pmid: 7977546].
Chung TK, Haines CJ, Rogers MS, Chang AM. The influence of obstetric workload on cesarean section rate. Asia Oceania J Obstet Gynaecol. 1994;20(3):295-300. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE4. [pmid: 7811197].
Clark SL. Elective induction: an analysis of economic and health consequences. Am J Obstet Gynecol. 2003;188(6):1664-5. author reply 1665. Notes: Harms Search; Comment Letter. AI. FTE3. FTE6. DA. [pmid: 12825016].
Cnattingius R, Cnattingius S, Notzon FC. Obstacles to reducing cesarean rates in a low-cesarean setting: the effect of maternal age, height, and weight. Obstet Gynecol. 1998;92(4 Pt 1):501-6. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 9764619].
Cochrane D, Aronyk K, Sawatzky B, Wilson D, Steinbok P. The effects of labor and delivery on spinal cord function and ambulation in patients with meningomyelocele. Childs Nerv Syst. 1991;7(6):312-5. Notes: infant and c-section additions. AI. FTE6. [pmid: 1764706].
Cogliano MS, Graham AC, Clark VA. Supplementary oxygen administration for elective Caesarean section under spinal anaesthesia. Anaesthesia. 2002;57(1):66-9. Notes: RCT Search; Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE6. FTE8. [pmid: 11843746].
Cole DS, Dayal AK, Chazotte C. Elective primary cesarean delivery. N Engl J Med. 2003;348(23):2364-5. author reply 2364–5. Notes: Harms Search; Comment Letter. AI. FTE3. FTE4. FTE5. FTE6. FTE7. BKGRD. [pmid: 12793417].
Combs CA, Singh NB, Khoury JC. Elective induction versus spontaneous labor after sonographic diagnosis of fetal macrosomia. Obstet Gynecol. 1993;81(4):492-6. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 8459954].
Compagnoni G, Lista G, Giuffre B, Mosca F, Marini A. Coenzyme Q10 levels in maternal plasma and cord blood:correlations with mode of delivery. Biol Neonate. 2004;86(2):104-7. Notes: Harms Search; Journal Article. AI. FTE6. FTE8. BKGRD. [pmid: 15133315].
Cooley S, Geary M, McDermott E, Keane DP. Colonic pseudo-obstruction following elective caesarean section. J Obstet Gynaecol. 2002;22(2):220. Notes: Harms Search; Case Reports Journal Article. AI. FTE6. FTE7. FTE8. [pmid: 12528700].
Cotzias CS,, Paterson-Brown S, Fisk NM. Obstetricians say yes to maternal request for elective caesarean section: a survey of current opinion. Eur J Obstet Gynecol Reprod Biol. 2001;97(1):15-6. Notes: KQ1 Search Journal Article. AI. FTE5. FTE6. BKGRD. [pmid: 11435000].
Coughlan C, Kearney R, Turner MJ. What are the implications for the next delivery in primigravidae who have an elective caesarean section for breech presentation?. Br J Obstet Gynaecol. 2002;109(6):624-6. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6.
Coulter CH, Lehrfeld R. When push comes to shove: implementing VBAC practice guidelines. Physician Exec. 1995;21(6):30-5. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE3. FTE6. FTE8. [pmid: 10161334].
Cowan RK, Kinch RA, Ellis B, Anderson R. Trial of labor following cesarean delivery. Obstet Gynecol. 1994;83(6):933-6. Notes: infant and c-section additions. AI. FTE6. DA. [pmid: 8190434].
Craigo S. Placenta previa with suspected accreta. Curr Opin Obstet Gynecol. 1997;9(1):71-5. Notes: Case Reports Journal Article Placenta Previa Search. AI. FTE3. FTE8. BKGRD. [pmid: 9090486].
Croughan-Minihane MS, Petitti DB, Gordis L, Golditch I. Morbidity among breech infants according to method of delivery. Obstet Gynecol. 1990;75(5):821-5. Notes: infant and c-section additions. AI. FTE6. [pmid: 2325965].
Daltveit AK, Vollset SE, Skjaerven R, Irgens LM. Impact of multiple births and elective deliveries on the trends in low birth weight in Norway, 1967-1995. Am J Epidemiol. 1999;149(12):1128-33. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 10369507].
Dani C, Reali MF, Oliveto R, Temporin GF, Bertini G, Rubaltelli FF. Short-term outcome of newborn infants born by a modified procedure of cesarean section. A prospective randomized study. Acta Obstet Gynecol Scand. 1998;77(9):929-31. Notes: Neonate outcome study Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE6. [pmid: 9808382].
Danielian P, Nikolaou D. The unfacts of “request” caesarean section. Br J Obstet Gynaecol. 2003;110(8):784. author reply 784–5. Notes: Harms Search; Comment Letter. AI. FTE3. BKGRD.
Dansereau J, Joshi AK, Helewa ME, et al. Double-blind comparison of carbetocin versus oxytocin in prevention of uterine atony after cesarean section. Am J Obstet Gynecol. 1999;180(3 Pt 1):670-6. Notes: RCT Search; Clinical Trial Journal Article Multicenter Study Randomized Controlled Trial. AI. FTE6. [pmid: 10076146].
Darj E, Nordstrom ML. The Misgav Ladach method for cesarean section compared to the Pfannenstiel method. Acta Obstet Gynecol Scand. 1999;78(1):37-41. Notes: RCT Search; Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE6. FTE8. BKGRD. [pmid: 9926890].
De Leeuw JW, Vierhout ME, Struijk PC, Hop WC, Wallenburg HC. Anal sphincter damage after vaginal delivery: functional outcome and risk factors for fecal incontinence. Acta Obstet Gynecol Scand. 2001;80(9):830-4. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 11531634].
Decca L, Daldoss C, Fratelli N, et al. Labor course and delivery in epidural analgesia: a case-control study. J Matern Fetal Neonatal Med. 2004;16(2):115-8. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. [pmid: 15512722].
Dehbashi S, Honarvar M, Fardi FH. Manual removal or spontaneous placental delivery and postcesarean endometritis and bleeding. Int J Gynaecol Obstet. 2004;86(1):12-5. Notes: Harms Search; RCT Search; Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE4. FTE6. [pmid: 15207663].
DeLancey JO. Childbirth, continence, and the pelvic floor. N Engl J Med. 1993;329(26):1956-7. Notes: Urinary Incontinence Search; Comment Editorial. AI. FTE3. FTE4. FTE5. FTE6. FTE7. FTE8. BKGRD. [pmid: 8247060].
Demirci F, Ozden S, Alpay Z, Demirci ET, Ayas S. The effects of vaginal delivery and cesarean section on bladder neck mobility and stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):129-33. Notes: Urinary Incontinence Search; Journal Article. AI. FTE4. [pmid: 11374511].
Demott RK. A blatant misuse of power?. Birth. 2000;27(4):264-5. Notes: Harms Search; Comment Journal Article. AI. FTE3. FTE4. FTE5. FTE6. FTE7. FTE8. BKGRD. [pmid: 11251512].
Dewey KG, Nommsen-Rivers LA, Heinig MJ, Cohen RJ. Risk factors for suboptimal infant breastfeeding behavior, delayed onset of lactation, and excess neonatal weight loss. Pediatrics. 2003;112(3 Pt 1):607-19. Notes: infant and c-section additions. AI. FTE6. [pmid: 12949292].
Diaz SD, Jones JE, Seryakov M, Mann WJ. Uterine rupture and dehiscence: ten-year review and case-control study. South Med J. 2002;95(4):431-5. Notes: infant and c-section additions. AI. FTE6. FTE8. DA. [pmid: 11958242].
Dietz HP, Steensma AB. Which women are most affected by delivery-related changes in pelvic organ mobility?. Eur J Obstet Gynecol Reprod Biol. 2003;111(1):15-8. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. BKGRD. [pmid: 14557005].
Diro M,, Puangsricharern A, Royer L,, O'Sullivan MJ, Burkett G. Singleton term breech deliveries in nulliparous and multiparous women: a 5-year experience at the University of Miami/Jackson Memorial Hospital. Am J Obstet Gynecol. 1999;181(2):247-52. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE6. [pmid: 10454664].
Dodd J, Pearce E, Crowther C. Women's experiences and preferences following Caesarean birth. Aust N Z J Obstet Gynaecol. 2004;44(6):521-4. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE9. [pmid: 15598289].
Dodd J, Anderson E, Gates S. Surgical techniques involving the uterus at the time of caesarean section. Cochrane Database Syst Rev 2004; (2). Notes: (42) Cochrane Search Label: PBS Record: 170 AI FTE3
Dodd J, Crowther C. Elective repeat caesarean section versus induction of labour for women with a previous caesarean birth. Cochrane Database Syst Rev 2003; (3). Notes: (42) Cochrane Search Label: PBS Record: 70 AI FTE3
Donahue D, Brooten D, Roncoli M, et al. Acute care visits and rehospitalization in women and infants after cesarean birth. J Perinatol. 1994;14(1):36-40. Notes: infant and c-section additions. AI. FTE6. DA. [pmid: 8169676].
Douvier S, Ferrut O, Lancon J, Feldman J. Epidural vs spinal anesthesia effects on neonates for elective cesarean section. J Perinat Med. 1992;20(1):132. Notes: (42) EMBASE Search; Label: PBS Record: 580. AI. FTE10.
DuBard CA, Newton WP. Elective cesarean delivery to prevent vertical transmission of HIV. J Fam Pract. 1999;48(7):493-4. Notes: Harms Search; Journal Article. AI. FTE3. FTE6. FTE7. [pmid: 10428239].
Dubuc M, Crochetiere C, Villeneuve E. Ondansetron in the prevention of pruritis during elective cesarean section under spinal anesthesia [abstract]. Anesthesiology. 2001;94(1A):A91. Notes: Cochrane CCTR Search; EMBASE Search; Label: PBS Record: 170. AI. FTE6. FTE8.
Durnwald C, Mercer B. Uterine rupture, perioperative and perinatal morbidity after single-layer and double-layer closure at cesarean delivery. Am J Obstet Gynecol. 2003;189(4):925-9. Notes: Comparison Studies Journal Article. AI. FTE6. [pmid: 14586327].
Echt M, Begneaud W, Montgomery D. Effect of epidural analgesia on the primary cesarean section and forceps delivery rates. J Reprod Med. 2000;45(7):557-61. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 10948466].
Ecker JL, Chen KT, Cohen AP, Riley LE, Lieberman ES. Increased risk of cesarean delivery with advancing maternal age: indications and associated factors in nulliparous women. Am J Obstet Gynecol. 2001;185(4):883-7. Notes: Outcomes Studies; Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 11641671].
Ecker JL, Greenberg JA, Norwitz ER, Nadel AS, Repke JT. Birth weight as a predictor of brachial plexus injury. Obstet Gynecol. 1997;89(5 Pt 1):643-7. Notes: Harms Search; Journal Article. AI. FTE6. [pmid: 9166293].
Edwards RK, Harnsberger DS, Johnson IM, Treloar RW, Cruz AC. Deciding on route of delivery for obese women with a prior cesarean delivery. Am J Obstet Gynecol. 2003;189(2):385-9. discussion 389–90. Notes: Harms Search; Journal Article. AI. FTE6. [pmid: 14520202].
Eggesbo M, Botten G, Stigum H, Nafstad P, Magnus P. Is delivery by cesarean section a risk factor for food allergy?. J Allergy Clin Immunol. 2003;112(2):420-6. Notes: infant and c-section additions. AI. FTE6. [pmid: 12897751].
Elferink-Stinkens PM, Brand R, Van Hemel OJ. Trends in caesarean section rates among high- and medium-risk pregnancies in The Netherlands 1983-1992. Eur J Obstet Gynecol Reprod Biol. 1995;59(2):159-67. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. [pmid: 7657010].
Elliott JP, Istwan NB, Jacques DL, Coleman SK, Stanziano GJ. Consequences of nonindicated preterm delivery in singleton gestations. J Reprod Med. 2003;48(9):713-7. Notes: Harms Search; Journal Article. AI. FTE5. FTE6. [pmid: 14562637].
Erata YE, Kilic B, Guclu S, Saygili U, Uslu T. Risk factors for pelvic surgery. Arch Gynecol Obstet. 2002;267(1):14-8. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. BKGRD. [pmid: 12410367].
The European Mode of Delivery Collaboration. Elective caesarean-section versus vaginal delivery in prevention of vertical HIV-1 transmission: a randomised clinical trial. Lancet 1999; 353(9158):1035–9. Notes: Harms Search; RCT Search; Clinical Trial Journal Article Multicenter Study Randomized Controlled Trial AI FTE5 FTE6
European Paediatric Hepatitis C Virus Network. Effects of mode of delivery and infant feeding on the risk of mother-to-child transmission of hepatitis C virus. Br J Obstet Gynaecol 2001; 108(4):371–7. Notes: Harms Search; European Paediatric Hepatitis C Virus Network. Journal Article Multicenter Study AI FTE6
Evans KC, Evans RG, Royal R, Esterman AJ, James SL. Effect of caesarean section on breast milk transfer to the normal term newborn over the first week of life. Arch Dis Child Fetal Neonatal Ed. 2003;88(5):F380-2. Notes: infant and c-section additions. AI. FTE6. [pmid: 12937041].
Faiz AS, Ananth CV. Etiology and risk factors for placenta previa: an overview and meta-analysis of observational studies. J Matern Fetal Neonatal Med. 2003;13(3):175-90. Notes: Journal Article Meta-Analysis Placenta Previa Search. AI. FTE3. FTE6. [pmid: 12820840].
Faundes A, Guarisi T, Pinto-Neto AM. The risk of urinary incontinence of parous women who delivered only by cesarean section. Int J Gynaecol Obstet. 2001;72(1):41-6. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 11146076].
Fisler RE, Cohen A, Ringer SA, Lieberman E. Neonatal outcome after trial of labor compared with elective repeat cesarean section. Birth. 2003;30(2):83-8. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 12752164].
Flamm BL, Goings JR, Liu Y, WoldeTsadik G. Elective repeat cesarean delivery versus trial of labor: a prospective multicenter study. Obstet Gynecol. 1994;83(6):927-32. Notes: Harms Search; Clinical Trial Journal Article Multicenter Study. AI. FTE6. [pmid: 8190433].
Fogelson NS, Menard MK, Hulsey T, et al. Neonatal impact of elective repeat cesarean delivery at term: a comment on patient choice cesarean delivery. Am J Obstet Gynecol. 2005;192(5):1433-6. Notes: HAND SEARCH. AI. FTE6. [pmid: 15902129].
Foldspang A, Hvidman L, Mommsen S, Nielsen JB. Risk of postpartum urinary incontinence associated with pregnancy and mode of delivery. Acta Obstet Gynecol Scand. 2004;83(10):923-7. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. BKGRD. [pmid: 15453887].
Foldspang A, Mommsen S, Djurhuus JC. Prevalent urinary incontinence as a correlate of pregnancy, vaginal childbirth, and obstetric techniques. Am J Public Health. 1999;89(2):209-12. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 9949751]. [pmcid: 1508519].
Forna F, Miles AM, Jamieson DJ. Emergency peripartum hysterectomy: a comparison of cesarean and postpartum hysterectomy. Am J Obstet Gynecol. 2004;190(5):1440-4. Notes: Comparison Studies Journal Article. AI. FTE6. FTE8. BKGRD. [pmid: 15167863].
Fraser W, Maunsell E, Hodnett E, Moutquin JM. Randomized controlled trial of a prenatal vaginal birth after cesarean section education and support program. Childbirth Alternatives Post-Cesarean Study Group. Am J Obstet Gynecol. 1997;176(2):419-25. Notes: RCT Search; KQ1 Search Clinical Trial Journal Article Multicenter Study Randomized Controlled Trial. AI. FTE6. [pmid: 9065192].
Frederiksen MC, Glassenberg R, Stika CS. Placenta previa: a 22-year analysis. Am J Obstet Gynecol. 1999;180(6 Pt 1):1432-7. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 10368483].
French L. Trial of labor after cesarean section. J Fam Pract. 1996;43(6):538-9. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE3. FTE6. BKGRD. [pmid: 8969698].
French L, Smaill F. Antibiotic regimens for endometritis after delivery. Cochrane Database Syst Rev 2004; (4). Notes: (42) Cochrane Search Label: PBS Record: 30 AI FTE3
Fritel X, Fauconnier A, Levet C, Benifla JL. Stress urinary incontinence 4 years after the first delivery: a retrospective cohort survey. Acta Obstet Gynecol Scand. 2004;83(10):941-5. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 15453890].
Gagnon AJ, Waghorn K. One-to-one nurse labor support of nulliparous women stimulated with oxytocin. J Obstet Gynecol Neonatal Nurs. 1999;28(4):371-6. Notes: Comparison Studies Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE6.
Gauruder-Burmester A, Tunn R. Pregnancy and labor after TVT-plasty. Acta Obstet Gynecol Scand. 2001;80(3):283-4. Notes: Urinary Incontinence Search; Case Reports Journal Article. AI. FTE3. FTE5. FTE6. FTE7. FTE8. [pmid: 11207500].
Ghetti C, Chan BK, Guise JM. Physicians' responses to patient-requested cesarean delivery. Birth. 2004;31(4):280-4. Notes: KQ1 Search Journal Article. AI. FTE5. FTE6. [pmid: 15566340].
Gibb DM, Goodall RL, Dunn DT, et al. Mother-to-child transmission of hepatitis C virus: evidence for preventable peripartum transmission. Lancet. 2000;356(9233):904-7. Notes: Harms Search; Journal Article Multicenter Study. AI. FTE6. [pmid: 11036896].
Gielchinsky Y, Rojansky N, Fasouliotis SJ, Ezra Y. Placenta accreta—summary of 10 years: a survey of 310 cases. Placenta. 2002;23(23):210-4. Notes: Journal Article Placenta Previa Search. AI. FTE6. [pmid: 11945088].
Giuliani A, Scholl WM, Basver A, Tamussino KF. Mode of delivery and outcome of 699 term singleton breech deliveries at a single center. Am J Obstet Gynecol. 2002;187(6):1694-8. Notes: Outcomes Studies; Journal Article. AI. FTE6. [pmid: 12501085].
Glantz JC. Labor induction rate variation in upstate New York: what is the difference?. Birth. 2003;30(3):168-74. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 12911799].
Gofton EN, Capewell V, Natale R, Gratton RJ. Obstetrical intervention rates and maternal and neonatal outcomes of women with gestational hypertension. Am J Obstet Gynecol. 2001;185(4):798-803. Notes: Comparison Studies Journal Article. AI. FTE6. [pmid: 11641654].
Gonen R, Bader D, Ajami M. Effects of a policy of elective cesarean delivery in cases of suspected fetal macrosomia on the incidence of brachial plexus injury and the rate of cesarean delivery. Am J Obstet Gynecol. 2000;183(5):1296-300. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 11084580].
Gonen R, Tamir A, Degani S. Obstetricians' opinions regarding patient choice in cesarean delivery. Obstet Gynecol. 2002;99(4):577-80. Notes: KQ1 Search Journal Article. AI. FTE5. FTE6. [pmid: 12039114].
Gonzalez F, Juliano S. Is pediatric attendance necessary for all cesarean sections?. J Am Osteopath Assoc. 2002;102(3):127-9. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 11926690].
Grant A, Penn ZJ, Steer PJ. Elective or selective caesarean delivery of the small baby? A systematic review of the controlled trials. Br J Obstet Gynaecol. 1996;103(12):1197-200. Notes: Harms Search; Meta-analysis Search; KQ1 Search Journal Article Meta-Analysis. AI. FTE3. [pmid: 8968235].
Gregory KD, Curtin SC, Taffel SM, Notzon FC. Changes in indications for cesarean delivery: United States, 1985 and 1994. Am J Public Health. 1998;88(9):1384-7. Notes: KQ1 Search Journal Article. AI. FTE11. [pmid: 9736883]. [pmcid: 1509079].
Gregory KD, Henry OA, Gellens AJ, Hobel CJ, Platt LD. Repeat cesareans: how many are elective?. Obstet Gynecol. 1994;84(4):574-8. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 8090395].
Gregory KD, Korst LM, Gornbein JA, Platt LD. Using administrative data to identify indications for elective primary cesarean delivery. Health Serv Res. 2002;37(5):1387-401. Notes: KQ1 Search Journal Article. AI. FTE6. BKGRD. [pmid: 12479502]. [pmcid: 1464023].
Gribble RK, Meier PR. Effect of epidural analgesia on the primary cesarean rate. Obstet Gynecol. 1991;78(2):231-4. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 2067767].
Grobman WA, Peaceman AM, Socol ML. Cost-effectiveness of elective cesarean delivery after one prior low transverse cesarean. Obstet Gynecol. 2000;95(5):745-51. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE3. DA. [pmid: 10775741].
Groutz A, Fait G, Lessing JB, et al. Incidence and obstetric risk factors of postpartum anal incontinence. Scand J Gastroenterol. 1999;34(3):315-8. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 10232879].
Guinn DA, Goepfert AR, Christine M, Owen J, Hauth JC. Extra-amniotic saline, laminaria, or prostaglandin E(2) gel for labor induction with unfavorable cervix: a randomized controlled trial. Obstet Gynecol. 2000;96(1):106-12. Notes: KQ1 Search Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE6. [pmid: 10862852].
Gunasekera PC, Wijesinghe PS, Goonewardene IM. The caesarean section rate is rising. Ceylon Med J. 2001;46(4):147-50. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE3. FTE4. FTE8. [pmid: 12164034].
Gupta E, Neelakantan D, Dwarakanath LS, Gee H. Planned vaginal delivery versus elective caesarean section: a study of 705 singleton term breech presentations. Br J Obstet Gynaecol. 2000;107(8):1058. Notes: Harms Search; Comment Letter. AI. FTE3. FTE5. FTE6.
Gurel H, Gurel SA. Pelvic relaxation and associated risk factors: the results of logistic regression analysis. Acta Obstet Gynecol Scand. 1999;78(4):290-3. Notes: Urinary Incontinence Search; Journal Article. AI. FTE4. FTE6. [pmid: 10203294].
Haley J, Tuffnell DJ, Johnson N. Randomised controlled trial of cardiotocography versus umbilical artery Doppler in the management of small for gestational age fetuses. Br J Obstet Gynaecol. 1997;104(4):431-5. Notes: Comparison Studies Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE6. [pmid: 9141579].
Hall J. From the United Kingdom. Midwifery Today Int Midwife 2002; (61):61–2. Notes: infant and c-section additions AI FTE3 FTE6
Hall MH. Mortality associated with elective caesarean section. Br Med J. 1994;308(6943):1572. Notes: Harms Search; Letter. AI. FTE3. FTE6. [pmid: 8019334].
Handa VL, Harvey L, Fox HE, Kjerulff KH. Parity and route of delivery: does cesarean delivery reduce bladder symptoms later in life?. Am J Obstet Gynecol. 2004;191(2):463-9. Notes: Urinary Incontinence Search; Journal Article Multicenter Study. AI. FTE6. [pmid: 15343222].
Handler AS, Mason ED, Rosenberg DL, Davis FG. The relationship between exposure during pregnancy to cigarette smoking and cocaine use and placenta previa. Am J Obstet Gynecol. 1994;170(3):884-9. Notes: Journal Article Placenta Previa Search. AI. FTE6. BKGRD. DA. [pmid: 8141221].
Hannah ME. Planned elective cesarean section: a reasonable choice for some women?. Can Med Assoc J. 2004;170(5):813-4. Notes: Harms Search; Comment Journal Article. AI. FTE3. FTE7. BKGRD. [pmid: 14993177]. [pmcid: 343856].
Hannah ME, Huh C, Hewson SA, Hannah WJ. Postterm pregnancy: putting the merits of a policy of induction of labor into perspective. Birth. 1996;23(1):13-9. Notes: Comparison Studies Clinical Trial Journal Article Multicenter Study Randomized Controlled Trial. AI. FTE6. [pmid: 8703252].
Hansell RS, McMurray KB, Huey GR. Vaginal birth after two or more cesarean sections: a five-year experience. Birth. 1990;17(3):146-50. discussion 150–1. Notes: Outcomes Studies; Journal Article. AI. FTE6. [pmid: 2222640].
Harper MA, Byington RP, Espeland MA, et al. Pregnancy-related death and health care services. Obstet Gynecol. 2003;102(2):273-8. Notes: HAND SEARCH. AI. FTE6. BKGRD. [pmid: 12907099].
Harwood MI. Are there adverse maternal and neonatal outcomes associated with induction of labor when there is no well-accepted indication?. J Fam Pract. 2001;50(2):106. Notes: Outcomes Studies; Harms Search; KQ1 Search Journal Article. AI. FTE6. BKGRD. [pmid: 11219552].
Heikkila A, Heinonen S, Kirkinen P. Maternal serum second trimester AFP and hCG in pregnancies with placenta previa. Prenat Diagn. 2000;20(2):100-2. Notes: PREVIA UPDATE. AI. FTE11. [pmid: 10694682].
Heinberg EM, Wood RA, Chambers RB. Elective induction of labor in multiparous women. Does it increase the risk of cesarean section?. J Reprod Med. 2002;47(5):399-403. Notes: Outcomes Studies; Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 12063879].
Hemminki E. Long term maternal health effects of caesarean section. J Epidemiol Community Health. 1991;45(1):24-8. Notes: Comparison Studies Journal Article. AI. FTE6. [pmid: 2045740]. [pmcid: 1060697].
Hemminki E, Gissler M. Epidural analgesia as a risk factor for operative delivery. Int J Gynaecol Obstet. 1996;53(2):125-32. Notes: Outcomes Studies; Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 8735292].
Hemminki E, Merilainen J. Long-term effects of cesarean sections: ectopic pregnancies and placental problems. Am J Obstet Gynecol. 1996;174(5):1569-74. Notes: Journal Article Placenta Previa Search. AI. FTE6. BKGRD. DA. [pmid: 9065131].
Hendricks MS, Chow YH, Bhagavath B, Singh K. Previous cesarean section and abortion as risk factors for developing placenta previa. J Obstet Gynaecol Res. 1999;25(2):137-42. Notes: Journal Article Placenta Previa Search. AI. FTE4. FTE6. [pmid: 10379130].
Henry OA, Gregory KD, Hobel CJ, Platt LD. Using ICD-9 codes to identify indications for primary and repeat cesarean sections: agreement with clinical records. Am J Public Health. 1995;85(8 Pt 1):1143-6. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 7625515]. [pmcid: 1615835].
Herbst A, Thorngren-Jerneck K. Mode of delivery in breech presentation at term: increased neonatal morbidity with vaginal delivery. Acta Obstet Gynecol Scand. 2001;80(8):731-7. Notes: Outcomes Studies; Journal Article. AI. FTE6. [pmid: 11531616].
Hershkowitz R, Fraser D, Mazor M, Leiberman JR. One or multiple previous cesarean sections are associated with similar increased frequency of placenta previa. Eur J Obstet Gynecol Reprod Biol. 1995;62(2):185-8. Notes: Journal Article Placenta Previa Search. AI. FTE6. BKGRD. [pmid: 8582493].
Hibbard JU, Ismail MA, Wang Y, Te C, Karrison T. Failed vaginal birth after a cesarean section: how risky is it? I. Maternal morbidity. Am J Obstet Gynecol. 2001;184(7):1365-71. discussion 1371–3. Notes: Harms Search; Journal Article. AI. FTE6. [pmid: 11408854].
Hickey K, Byrne P. Planned abdominal compared with planned vaginal birth in triplet pregnancies. Br J Obstet Gynaecol. 1995;102(11):937-8. Notes: Harms Search; Comment Letter. AI. FTE3. FTE4. FTE5. FTE6. FTE7. FTE8. [pmid: 8534640].
Hilder L, Costeloe K, Thilaganathan B. Prolonged pregnancy: evaluating gestation-specific risks of fetal and infant mortality. Br J Obstet Gynaecol. 1998;105(2):169-73. Notes: HAND SEARCH. AI. FTE6. [pmid: 9501781].
Hillan E. Caesarean section: perinatal risks. Nurs Stand. 1991;5(49):37-9. Notes: infant and c-section additions. AI. FTE10. [pmid: 1809366].
Hillan EM. Short-term morbidity associated with cesarean delivery. Birth. 1992;19(4):190-4. Notes: infant and c-section additions. AI. FTE6. [pmid: 1472266].
Hiremath VS, Gaffney G. Audit of thromboprophylaxis following caesarean section. Ir Med J. 2000;93(8):234-6. Notes: Harms Search; Journal Article. AI. FTE6. [pmid: 11133055].
Hod M, Bar J, Peled Y, et al. Antepartum management protocol. Timing and mode of delivery in gestational diabetes. Diabetes Care. 1998;21(Suppl 2):B113-7. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. [pmid: 9704237].
Hodnett ED, Lowe NK, Hannah ME, et al. Effectiveness of nurses as providers of birth labor support in North American hospitals: a randomized controlled trial. J Am Med Assoc. 2002;288(11):1373-81. Notes: Neonate outcome study Nursing Supportive Care in Labor Trial Group. Clinical Trial Journal Article Multicenter Study Randomized Controlled Trial. AI. FTE6.
Hojberg KE, Salvig JD, Winslow NA, Lose G, Secher NJ. Urinary incontinence: prevalence and risk factors at 16 weeks of gestation. Br J Obstet Gynaecol. 1999;106(8):842-50. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. BKGRD. [pmid: 10453836].
Holubkov R, Holt VL, Connell FA, LoGerfo JP. Analysis, assessment, and presentation of risk-adjusted statewide obstetrical care data: the StORQS II study in Washington State. Statewide Obstetrics Review and Quality System. Health Serv Res. 1998;33(3 Pt 1):531-48. Notes: infant and c-section additions. AI. FTE5. FTE6. FTE7. FTE8. [pmid: 9685121]. [pmcid: 1070275].
Homer CS, Davis GK, Brodie PM, et al. Collaboration in maternity care: a randomised controlled trial comparing community-based continuity of care with standard hospital care. Br J Obstet Gynaecol. 2001;108(1):16-22. Notes: Neonate outcome study Clinical Trial Journal Article Randomized Controlled Trial. AI. FTE6.
Hong JY. Comparison of preoperative gastric content and risk factors in elective and intrapartum Cesarean delivery. Can J Anaesth. 2004;51(7):742-3. Notes: Harms Search; Clinical Trial Letter. AI. FTE4. FTE5. FTE6. FTE7. FTE8. [pmid: 15310650].
Hook B, Kiwi R, Amini SB, Fanaroff A, Hack M. Neonatal morbidity after elective repeat cesarean section and trial of labor. Pediatrics. 1997;100(3 Pt 1):348-53. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE6. [pmid: 9282704].
Hopkins L, Smaill F. Antibiotic prophylaxis regimens and drugs for cesarean section. Cochrane Database Syst Rev 1999; (1). Notes: (42) Cochrane CCTR Search Label: PBS Record: 20 AI FTE3
How HY, Harris BJ, Pietrantoni M, et al. Is vaginal delivery preferable to elective cesarean delivery in fetuses with a known ventral wall defect?. Am J Obstet Gynecol. 2000;182(6):1527-34. Notes: Outcomes Studies; Journal Article. AI. FTE11. [pmid: 10871475].
Howes V, Hardie K. Lambs to the slaughter. Pract Midwife. 2004;7(7):45-6. Notes: infant and c-section additions. AI. FTE10. [pmid: 15323343].
Hudson CN. Elective caesarean section for prevention of vertical transmission of HIV-1 infectionElective caesarean section for prevention of vertical transmission of HIV-1 infection. Lancet. 1999;353(9158):1030-1. Notes: Harms Search; Comment Journal Article. AI. FTE3. FTE4. FTE7. FTE8. [pmid: 10199345].
Hueston WJ, Applegate JA, Mansfield CJ, King DE, McClaflin RR. Practice variations between family physicians and obstetricians in the management of low-risk pregnancies. J Fam Pract. 1995;40(4):345-51. Notes: Outcomes Studies; Journal Article Multicenter Study. AI. FTE6. [pmid: 7699347].
Hueston WJ, McClaflin RR, Claire E. Variations in cesarean delivery for fetal distress. J Fam Pract. 1996;43(5):461-7. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 8917145].
Hueston WJ, Rudy M. Factors predicting elective repeat cesarean delivery. Obstet Gynecol. 1994;83(5 Pt 1):741-4. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 8164936].
Hvidman L, Foldspang A, Mommsen S, Nielsen JB. Postpartum urinary incontinence. Acta Obstet Gynecol Scand. 2003;82(6):556-63. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. BKGRD. [pmid: 12780427].
Iglesias S, Burn R, Saunders LD. Reducing the cesarean section rate in a rural community hospital. Can Med Assoc J. 1991;145(11):1459-64. Notes: HAND SEARCH. AI. FTE6. [pmid: 1959105]. [pmcid: 1336036].
Ilnyckyji A, Blanchard JF, Rawsthorne P, Bernstein CN. Perianal Crohn's disease and pregnancy: role of the mode of delivery. Am J Gastroenterol. 1999;94(11):3274-8. Notes: Outcomes Studies; Journal Article. AI. FTE6. FTE8. [pmid: 10566729].
Imberti R, Preseglio I, Trotta V, Filisetti P, Mapelli A. Blood transfusion during cesarean section. A 12 years' retrospective analysis. Acta Anaesthesiol Belg. 1990;41(2):139-44. Notes: Journal Article Placenta Previa Search. AI. FTE9. [pmid: 2371803].
The International Perinatal HIV Group. The mode of delivery and the risk of vertical transmission of human immunodeficiency virus type 1—a meta-analysis of 15 prospective cohort studies. N Engl J Med 1999; 340(13):977–87. Notes: Harms Search; Meta-analysis Search; KQ1 Search Journal Article Meta-Analysis AI FTE3 FTE6
Ismail MA, Nagib N, Ismail T, Cibils LA. Comparison of vaginal and cesarean section delivery for fetuses in breech presentation. J Perinat Med. 1999;27(5):339-51. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE6. [pmid: 10642954].
The Italian Collaborative Study on HIV Infection in Pregnancy. Mother-to-child transmission of human immunodeficiency virus in Italy: temporal trends and determinants of infection. Hum Reprod 1999; 14(1):242–6. Notes: Harms Search; Journal Article Multicenter Study AI FTE6
Jaillard S, Houfflin-Debarge V, Storme L. Higher risk of persistent pulmonary hypertension of the newborn after cesarean. J Perinat Med. 2003;31(6):538-9. Notes: Harms Search; Letter. AI. FTE3. FTE5. FTE6. FTE7. BKGRD. [pmid: 14711114].
James M, Hunt K, Burr R, Johanson R. A decision analytical cost analysis of offering ECV in a UK district general hospital. BMC Health Serv Res. 2001;1(1):6. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE3. FTE6. FTE7. FTE8. DA. [pmid: 11472641]. [pmcid: 35287].
Japaraj RP, Amaraddio D, Yee CF. Antenatal diagnosis of vasa praevia—need for a high index of suspicion. Aust N Z J Obstet Gynaecol. 2002;42(2):213-6. Notes: PREVIA UPDATE. AI. FTE11. [pmid: 12069154].
Jenkins JG, Khan MM. Anaesthesia for Caesarean section: a survey in a UK region from 1992 to 2002. Anaesthesia. 2003;58(11):1114-8. Notes: KQ1 Search Journal Article Multicenter Study. AI. FTE6. [pmid: 14616600].
Johanson R, Newburn M. Promoting normality in childbirth. Br Med J. 2001;323(7322):1142-3. Notes: Urinary Incontinence Search; Editorial. AI. FTE3. FTE6. [pmid: 11711387]. [pmcid: 1121633].
Johanson RB, El-Timini S, Rigby C, Young P, Jones P. Caesarean section by choice could fulfil the inverse care law. Eur J Obstet Gynecol Reprod Biol. 2001;97(1):20-2. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE5. FTE6. BKGRD. [pmid: 11435002].
Johnson R, Slade P. Does fear of childbirth during pregnancy predict emergency caesarean section?. Br J Obstet Gynaecol. 2002;109(11):1213-21. Notes: Outcomes Studies; Harms Search; KQ1 Search Journal Article. AI. FTE6.
Jozwik M. Partial denervation of the pelvic floor during term vaginal delivery. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):81-2. Notes: Urinary Incontinence Search; Editorial. AI. FTE3. FTE6. [pmid: 11374517].
Jurcevic P, Grover S, Henderson J. A reassessment of options for the management of placenta praevia percreta. Aust N Z J Obstet Gynaecol. 2002;42(1):84-8. Notes: PREVIA UPDATE. AI. FTE11. [pmid: 11926648].
Kacmar J, Bhimani L, Boyd M, Shah-Hosseini R, Peipert J. Route of delivery as a risk factor for emergent peripartum hysterectomy: a case-control study. Obstet Gynecol. 2003;102(1):141-5. Notes: infant and c-section additions. AI. FTE6. DA. [pmid: 12850620].
Kalish RB, McCullough L, Gupta M, et al. Intrapartum elective cesarean delivery: a previously unrecognized clinical entity. Obstet Gynecol. 2004;103(6):1137-41. Notes: KQ1 Search Journal Article. AI. FTE5. FTE6. [pmid: 15172844].
Karlowicz MG. Long-term pulmonary consequences of elective cesarean delivery. J Am Med Assoc. 2002;288(11):1352. author reply 1352. Notes: Harms Search; Comment Letter. AI. FTE3. BKGRD.
Kastner ES, Figueroa R, Garry D, Maulik D. Emergency peripartum hysterectomy: experience at a community teaching hospital. Obstet Gynecol. 2002;99(6):971-5. Notes: Journal Article Placenta Previa Search. AI. FTE6. BKGRD. [pmid: 12052583].
Kaufman KE, Bailit JL, Grobman W. Elective induction: an analysis of economic and health consequences. Am J Obstet Gynecol. 2002;187(4):858-63. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE3. FTE6. DA. [pmid: 12388964].
Kaufmann T. The rising caesarean rate: causes and effects for public health. RCM Midwives J. 2001;4(1):24-6. Notes: infant and c-section additions. AI. FTE10. [pmid: 12357745].
Kearney MH, Cronenwett LR, Reinhardt R. Cesarean delivery and breastfeeding outcomes. Birth. 1990;17(2):97-103. Notes: HAND SEARCH. AI. FTE6. [pmid: 2363774].
Keszler M, Carbone MT, Cox C, Schumacher RE. Severe respiratory failure after elective repeat cesarean delivery: a potentially preventable condition leading to extracorporeal membrane oxygenation. Pediatrics. 1992;89(4 Pt 1):670-2. Notes: infant and c-section additions. AI. FTE6. [pmid: 1557250].
Khadra M, Obhrai M, Keriakos R, Johanson R. Placenta percreta revisited. J Obstet Gynaecol. 2002;22(6):689. Notes: Case Reports Journal Article Placenta Previa Search. AI. FTE10. [pmid: 12554271].
Khong TY, Healy DL, McCloud PI. Pregnancies complicated by abnormally adherent placenta and sex ratio at birth. Br Med J. 1991;302(6777):625-6. Notes: Journal Article Placenta Previa Search. AI. FTE6. [pmid: 2012876]. [pmcid: 1675457].
Kitzinger S. Sheila Kitzinger's letter from Europe: the cesarean epidemic in Great Britain. Birth. 1998;25(1):56-8. Notes: KQ1 Search Journal Article. AI. FTE3. FTE6. BKGRD. [pmid: 9534507].
Kline J, Arias F. Analysis of factors determining the selection of repeated cesarean section or trial of labor in patients with histories of prior cesarean delivery. J Reprod Med. 1993;38(4):289-92. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 8501737].
Koike T, Minakami H, Sasaki M, Sayama M, Tamada T, Sato I. The problem of relating fetal outcome with breech presentation to mode of delivery. Arch Gynecol Obstet. 1996;258(3):119-23. Notes: Harms Search; Journal Article. AI. FTE6. [pmid: 8781699].
Kolas T, Hofoss D, Daltveit AK, et al. Indications for cesarean deliveries in Norway. Am J Obstet Gynecol. 2003;188(4):864-70. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. BKGRD. [pmid: 12712077].
Kolderup LB, Laros RK Jr, Musci TJ. Incidence of persistent birth injury in macrosomic infants: association with mode of delivery. Am J Obstet Gynecol. 1997;177(1):37-41. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE6. BKGRD. [pmid: 9240580].
Koo MR, Dekker GA, van Geijn. Perinatal outcome of singleton term breech deliveries. Eur J Obstet Gynecol Reprod Biol. 1998;78(1):19-24. Notes: Outcomes Studies; Journal Article. AI. FTE6. [pmid: 9605443].
Koroukian SM, Rimm AA. Declining trends in cesarean deliveries, Ohio 1989-1996: an analysis by indications. Birth. 2000;27(1):12-8. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE11. [pmid: 10865555].
Kostash MA, Mensink F. Lethal air embolism during cesarean delivery for placenta previa. Anesthesiology. 2002;96(3):753-4. Notes: PREVIA UPDATE. AI. FTE11. [pmid: 11873053].
Krebs L, Langhoff-Roos J, Weber T. Breech at term—mode of delivery? A register-based study. Acta Obstet Gynecol Scand. 1995;74(9):702-6. Notes: Outcomes Studies; Journal Article. AI. FTE6. BKGRD. [pmid: 7572104].
Krebs L, Topp M, Langhoff-Roos J. The relation of breech presentation at term to cerebral palsy. Br J Obstet Gynaecol. 1999;106(9):943-7. Notes: infant and c-section additions. AI. FTE6. BKGRD. [pmid: 10492106].
Kritchevsky SB, Braun BI, Gross PA, Newcomb CS, Kelleher CA, Simmons BP. Definition and adjustment of Cesarean section rates and assessments of hospital performance. Int J Qual Health Care. 1999;11(4):283-91. Notes: Comparison Studies Journal Article Multicenter Study. AI. FTE5. FTE6. FTE7. FTE8. BKGRD. [pmid: 10501598].
Kumari AS, Badrinath P. Extreme grandmultiparity: is it an obstetric risk factor?. Eur J Obstet Gynecol Reprod Biol. 2002;101(1):22-5. Notes: PREVIA UPDATE. AI. FTE11. [pmid: 11803095].
Kumari AS, Grundsell H. Mode of delivery for breech presentation in grandmultiparous women. Int J Gynaecol Obstet. 2004;85(3):234-9. Notes: Outcomes Studies; Journal Article. AI. FTE4. FTE7. [pmid: 15145257].
Kwee A, Cohlen BJ, Kanhai HH, Bruinse HW, Visser GH. Caesarean section on request: a survey in The Netherlands. Eur J Obstet Gynecol Reprod Biol. 2004;113(2):186-90. Notes: KQ1 Search Journal Article. AI. FTE5. FTE6. [pmid: 15063958].
Lam H, Pun TC, Lam PW. Successful conservative management of placenta previa accreta during cesarean section. Int J Gynaecol Obstet. 2004;86(1):31-2. Notes: PREVIA UPDATE. AI. FTE. [pmid: 15207668].
Land R, Parry E, Rane A, Wilson D. Personal preferences of obstetricians towards childbirth. Aust N Z J Obstet Gynaecol. 2001;41(3):249-52. Notes: Urinary Incontinence Search; Harms Search; KQ1 Search Journal Article. AI. FTE5. FTE6. [pmid: 11592537].
Landon MB, Hauth JC, Leveno KJ, et al. Maternal and perinatal outcomes associated with a trial of labor after prior cesarean delivery. N Engl J Med. 2004;351(25):2581-9. Notes: Outcomes Studies; Harms Search; National Institute of Child Health and Human Development Maternal-Fetal Medicine Units Network.Journal ArticleMulticenter Study. AI. FTE6. [pmid: 15598960].
Langford R. Continence. Behind closed doors. Nurs Times. 1996;92(24):72. Notes: Urinary Incontinence Search; Congresses. AI. FTE3. FTE6. FTE4. FTE5. [pmid: 8716200].
Lashen H, Fear K, Sturdee D. Trends in the management of the breech presentation at term; experience in a District General hospital over a 10-year period. Acta Obstet Gynecol Scand. 2002;81(12):1116-22. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. [pmid: 12519107].
Lavery S, Harvey D. Neonatal respiratory morbidity and mode of delivery at term: influence of timing of elective cesarean section. Br J Obstet Gynaecol. 1995;102(10):843. Notes: Harms Search; CommentLetter. AI. FTE3. [pmid: 7547750].
Leeman L, Leeman R. A Native American community with a 7% cesarean delivery rate: does case mix, ethnicity, or labor management explain the low rate?. Ann Fam Med. 2003;1(1):36-43. Notes: Comparison Studies Journal Article. AI. FTE6. [pmid: 15043178]. [pmcid: 1466550].
Leiberman JR, Fraser D, Kasis A, Mazor M. Reduced frequency of hypertensive disorders in placenta previa. Obstet Gynecol. 1991;77(1):83-6. Notes: Journal Article Placenta Previa Search. AI. FTE6. [pmid: 1984232].
Levy R, Ferber A, Ben-Arie A, et al. A randomised comparison of early versus late amniotomy following cervical ripening with a Foley catheter. Br J Obstet Gynaecol. 2002;109(2):168-72. Notes: Comparison Studies Clinical TrialJournal ArticleRandomized Controlled Trial. AI. FTE6.
Li DK, Wi S. Maternal placental abnormality and the risk of sudden infant death syndrome. Am J Epidemiol. 1999;149(7):608-11. Notes: Journal Article Placenta Previa Search. AI. FTE6. [pmid: 10192307].
Liebling RE, Swingler R, Patel RR, Verity L, Soothill PW, Murphy DJ. Pelvic floor morbidity up to one year after difficult instrumental delivery and cesarean section in the second stage of labor: a cohort study. Am J Obstet Gynecol. 2004;191(1):4-10. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 15295337].
Lilford RJ, van Coeverden de Groot HA, Moore PJ, Bingham P. The relative risks of caesarean section (intrapartum and elective) and vaginal delivery: a detailed analysis to exclude the effects of medical disorders and other acute pre-existing physiological disturbances. Br J Obstet Gynaecol. 1990;97(10):883-92. Notes: KQ1 Search Journal Article. AI. FTE4. [pmid: 2223678].
Liu S, Rusen ID, Joseph KS, et al. Recent trends in caesarean delivery rates and indications for caesarean delivery in Canada. J Obstet Gynaecol Can. 2004;26(8):735-42. Notes: KQ1 Search Maternal Health Study Group of the Canadian Perinatal Surveillance System.Journal Article. AI. FTE6. [pmid: 15307978].
Locatelli A, Regalia AL, Ghidini A, Ciriello E, Biffi A, Pezzullo JC. Risks of induction of labour in women with a uterine scar from previous low transverse caesarean section. Br J Obstet Gynaecol. 2004;111(12):1394-9. Notes: Comparison Studies Journal Article. AI. FTE6.
Loebel G, Zelop CM, Egan JF, Wax J. Maternal and neonatal morbidity after elective repeat Cesarean delivery versus a trial of labor after previous Cesarean delivery in a community teaching hospital. J Matern Fetal Neonatal Med. 2004;15(4):243-6. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE6. [pmid: 15280132].
Lomas J, Enkin M, Anderson GM, Hannah WJ, Vayda E, Singer J. Opinion leaders vs audit and feedback to implement practice guidelines. Delivery after previous cesarean section. J Am Med Assoc. 1991;265(17):2202-7. Notes: Comparison Studies Clinical TrialJournal ArticleRandomized Controlled Trial. AI. FTE5. FTE6. FTE8.
Longo DR, Land G, Schramm W, Fraas J, Hoskins B, Howell V. Consumer reports in health care. Do they make a difference in patient care?. J Am Med Assoc. 1997;278(19):1579-84. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. FTE5. FTE8.
Lovell R. Vaginal delivery after Caesarean section: factors influencing success rates. Aust N Z J Obstet Gynaecol. 1996;36(1):4-8. Notes: Outcomes Studies; Journal Article. AI. FTE6. [pmid: 8775239].
Lubarsky SL, Schiff E, Friedman SA, Mercer BM, Sibai BM. Obstetric characteristics among nulliparas under age 15. Obstet Gynecol. 1994;84(3):365-8. Notes: Comparison Studies Journal Article. AI. FTE6. [pmid: 8058232].
Lubetzky R, Ben-Shachar S, Mimouni FB, Dollberg S. Mode of delivery and neonatal hematocrit. Am J Perinatol. 2000;17(3):163-5. Notes: Harms Search; Journal Article. AI. FTE6. FTE8. [pmid: 11012142].
Lumley JM. Unexplained antepartum stillbirth in pregnancies after a caesarean delivery. Lancet. 2003;362(9398):1774-5. Notes: infant and c-section additions. AI. FTE3. FTE6. FTE7. BKGRD. [pmid: 14654309].
Lurie S, Weissler A, Baider C, Hiaev Z, Sadan O, Glezerman M. Male fetuses and the risk of cesarean delivery. J Reprod Med. 2004;49(5):353-6. Notes: Harms Search; Journal Article. AI. FTE6. [pmid: 15214707].
Luthy DA, Malmgren JA, Zingheim RW. Cesarean delivery after elective induction in nulliparous women: the physician effect. Am J Obstet Gynecol. 2004;191(5):1511-5. Notes: Outcomes Studies; Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 15547518].
Luthy DA, Malmgren JA, Zingheim RW, Leininger CJ. Physician contribution to a cesarean delivery risk model. Am J Obstet Gynecol. 2003;188(6):1579-85. discussion 1585–7. Notes: Outcomes Studies; Harms Search; KQ1 Search Journal Article. AI. FTE6. BKGRD. [pmid: 12824996].
Lydon-Rochelle M, Holt VL, Easterling TR, Martin DP. First-birth cesarean and placental abruption or previa at second birth(1). Obstet Gynecol. 2001;97(5 Pt 1):765-9. Notes: Journal Article Placenta Previa Search. AI. FTE6. [pmid: 11339931].
Lydon-Rochelle M, Holt VL, Martin DP, et al. Association between method of delivery and maternal rehospitalization. J Am Med Assoc. 2000;283(18):2411-6. Notes: HAND SEARCH. AI. FTE6.
Lynch CM, Kearney R, Turner MJ. Maternal morbidity after elective repeat caesarean section after two or more previous procedures. Eur J Obstet Gynecol Reprod Biol. 2003;106(1):10-3. Notes: PREVIA UPDATEHarms Search. AE. FTE6. [pmid: 12475574].
Maberry MC, Gilstrap LC3, Bawdon R, Little BB, Dax J. Anaerobic coverage for intra-amnionic infection: maternal and perinatal impact. Am J Perinatol. 1991;8(5):338-41. Notes: Neonate outcome study Clinical TrialJournal ArticleRandomized Controlled Trial. AI. FTE6. [pmid: 1760067].
MacKenzie IZ, Cooke I, Annan B. Indications for caesarean section in a consultant obstetric unit over three decades. J Obstet Gynaecol. 2003;23(3):233-8. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. [pmid: 12850849].
MacLennan AH, Taylor AW, Wilson DH, Wilson D. The prevalence of pelvic floor disorders and their relationship to gender, age, parity and mode of delivery. Bjog. 2000;107(12):1460-70. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 11192101].
Macones GA, Cahill A, Pare E, et al. Obstetric outcomes in women with two prior cesarean deliveries: is vaginal birth after cesarean delivery a viable option?. Am J Obstet Gynecol. 2005;192(4):1223-8. discussion 1228–9. Notes: Comparison Studies Journal Article. AI. FTE6. [pmid: 15846208].
Madar J, Richmond S, Hey E. Surfactant-deficient respiratory distress after elective delivery at ‘term’. Acta Paediatr. 1999;88(11):1244-8. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 10591427].
Maher CF, Cave DG, Haran MV. Caesarean section rate reduced. Aust N Z J Obstet Gynaecol. 1994;34(4):389-92. Notes: KQ1 Search Journal Article. AI. FTE11. [pmid: 7848224].
Maitra A, Sherriff A, Strachan D, Henderson J. Mode of delivery is not associated with asthma or atopy in childhood. Clin Exp Allergy. 2004;34(9):1349-55. Notes: Harms Search; ALSPAC Study Team.Journal Article. AI. FTE6. [pmid: 15347366].
Malamitsi-Puchner A, Minaretzis D, Martzeli L, Papas C. Serum levels of creatine kinase and its isoenzymes during the 1st postpartum day in healthy newborns delivered vaginally or by cesarean section. Gynecol Obstet Invest. 1993;36(1):25-8. Notes: Outcomes Studies; Journal Article. AI. FTE6. [pmid: 8349174].
Malik A, Fenning N, O'Donnell E. Anal and urinary incontinence in women with obstetric anal sphincter rupture. Br J Obstet Gynaecol. 1997;104(6):753-4. Notes: Urinary Incontinence Search; CommentLetter. AI. FTE3. FTE6. BKGRD. [pmid: 9197889].
Marcickiewicz J. Comment to a case report in this issue of Acta regarding placenta previa percreta. Acta Obstet Gynecol Scand. 2004;83(1):4-5. Notes: PREVIA UPDATE. AI. FTE. [pmid: 14678079].
Marcollet A, Goffinet F, Firtion G, et al. Differences in postpartum morbidity in women who are infected with the human immunodeficiency virus after elective cesarean delivery, emergency cesarean delivery, or vaginal delivery. Am J Obstet Gynecol. 2002;186(4):784-9. Notes: Harms Search; Journal Article. AI. FTE6. DA. [pmid: 11967508].
Maslow AS, Sweeny AL. Elective induction of labor as a risk factor for cesarean delivery among low-risk women at term. Obstet Gynecol. 2000;95(6 Pt 1):917-22. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE6. [pmid: 10831992].
Mc Gurgan P, Coulter-Smith S, PJ OD. A national confidential survey of obstetrician's personal preferences regarding mode of delivery. Eur J Obstet Gynecol Reprod Biol. 2001;97(1):17-9. Notes: KQ1 Search Journal Article. AI. FTE5. FTE6. BKGRD. [pmid: 11435001].
McKenna DS, Ester JB, Fischer JR. Elective cesarean delivery for women with a previous anal sphincter rupture. Am J Obstet Gynecol. 2003;189(5):1251-6. Notes: Harms Search; Meta-analysis Search; KQ1 Search Journal ArticleMeta-Analysis. AI. FTE4. FTE5. FTE6. FTE7. FTE8. FTE3. BKGRD. DA. [pmid: 14634549].
McMahon MJ, Li R, Schenck AP, Olshan AF, Royce RA. Previous cesarean birth. A risk factor for placenta previa?. J Reprod Med. 1997;42(7):409-12. Notes: Journal Article Placenta Previa Search. AI. FTE6. [pmid: 9252931].
McMahon MJ, Luther ER, Bowes WA Jr, Olshan AF. Comparison of a trial of labor with an elective second cesarean section. N Engl J Med. 1996;335(10):689-95. Notes: Outcomes Studies; Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 8703167].
Melnikow J, Romano P, Gilbert WM, Schembri M, Keyzer J, Kravitz RL. Vaginal birth after cesarean in California. Obstet Gynecol. 2001;98(3):421-6. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 11530123].
Miller DA, Chollet JA, Goodwin TM. Clinical risk factors for placenta previa-placenta accreta. Am J Obstet Gynecol. 1997;177(1):210-4. Notes: Journal Article Placenta Previa Search. AI. FTE8. DA. [pmid: 9240608].
Minkoff H, Chervenak FA. Elective primary cesarean delivery. N Engl J Med. 2003;348(10):946-50. Notes: Harms Search; KQ1 Search CommentJournal Article. AI. FTE3. FTE4. FTE5. FTE6. FTE7. FTE8. BKGRD. [pmid: 12621140].
Moalli PA, Jones Ivy S, Meyn LA, Zyczynski HM. Risk factors associated with pelvic floor disorders in women undergoing surgical repair. Obstet Gynecol. 2003;101(5 Pt 1):869-74. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 12738142].
Mola GD. Symphysiotomy: technique, problems and pitfalls, and how to avoid them. P N G Med J. 1995;38(3):231-8. Notes: infant and c-section additions. AI. FTE3. FTE6. [pmid: 9522864].
Molkenboer JF, Bouckaert PX, Roumen FJ. Recent trends in breech delivery in the Netherlands. Br J Obstet Gynaecol. 2003;110(10):948-51. Notes: KQ1 Search Journal Article. AI. FTE6.
Monica G, Lilja C. Placenta previa, maternal smoking and recurrence risk. Acta Obstet Gynecol Scand. 1995;74(5):341-5. Notes: Journal Article Placenta Previa Search. AI. FTE6. [pmid: 7778424].
Mor-Yosef S, Samueloff A, Schenker JG. The Israel perinatal census. Asia Oceania J Obstet Gynaecol. 1992;18(2):139-45. Notes: infant and c-section additions. AI. FTE6. [pmid: 1503538].
Mortensen JT, Thulstrup AM, Larsen H, Moller M, Sorensen HT. Smoking, sex of the offspring, and risk of placental abruption, placenta previa, and preeclampsia: a population-based cohort study. Acta Obstet Gynecol Scand. 2001;80(10):894-8. Notes: Journal Article Placenta Previa Search. AE. FTE12. [pmid: 11580733].
Mozurkewich EL, Hutton EK. Elective repeat cesarean delivery versus trial of labor: a meta-analysis of the literature from 1989 to 1999. Am J Obstet Gynecol. 2000;183(5):1187-97. Notes: Meta-analysis Search Journal ArticleMeta-Analysis. AI. FTE3. [pmid: 11084565].
Mukherji J, Samaddar JC. How safe is caesarean section. J Obstet Gynaecol. 1995;21(1):17-21. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE4. FTE6. BKGRD. [pmid: 8591106].
Murphy DJ. Antepartum risk factors for newborn encephalopathy. Inverse association of risk may be due to easier delivery with elective caesarean section. Br Med J. 1999;318(7195):1414-15. Notes: Harms Search; CommentLetter. AI. FTE3. FTE6. FTE7. BKGRD.
Murphy JF. The relentless rise in caesarean sections. Ir Med J. 2001;94(7):196. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE3. BKGRD. [pmid: 11693205].
Murta EF, Nomelini RS. Is repeated caesarean section a consequence of elective caesarean section?. Lancet. 2004;364(9435):649-50. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE3. FTE4. FTE5. FTE6. FTE7. FTE8. BKGRD. [pmid: 15325816].
Naef RW3, Ray MA, Chauhan SP, Roach H, Blake PG, Martin JN Jr. Trial of labor after cesarean delivery with a lower-segment, vertical uterine incision: is it safe?. Am J Obstet Gynecol. 1995;172(6):1666-73. discussion 1673–4. Notes: Outcomes Studies; Harms Search; Clinical TrialJournal Article. AI. FTE6. [pmid: 7778619].
Negele K, Heinrich J, Borte M, et al. Mode of delivery and development of atopic disease during the first 2 years of life. Pediatr Allergy Immunol. 2004;15(1):48-54. Notes: infant and c-section additions. AI. FTE6. [pmid: 14998382].
Neri I, Airola G, Contu G, Allais G, Facchinetti F, Benedetto C. Acupuncture plus moxibustion to resolve breech presentation: a randomized controlled study. J Matern Fetal Neonatal Med. 2004;15(4):247-52. Notes: Neonate outcome study Clinical TrialJournal ArticleRandomized Controlled Trial. AI. FTE6. [pmid: 15280133].
Ng PC, Wong MY, Nelson EA. Paediatrician attendance at caesarean section. Eur J Pediatr. 1995;154(8):672-5. Notes: Harms Search; Journal Article. AI. FTE6. [pmid: 7588972].
Norman B, Crowhurst JA, Plaat F. Elective caesarean section on request. All types of anaesthesia carry risks. Br Med J. 1999;318(7176):120. Notes: Harms Search; CommentLetter. AI. FTE3. FTE5. FTE6. FTE7. FTE4. FTE8. BKGRD. [pmid: 10068228].
Nygaard I, Cruikshank DP. Should all women be offered elective cesarean delivery?. Obstet Gynecol. 2003;102(2):217-9. Notes: Harms Search; CommentEditorial. AI. FTE3. FTE4. FTE5. FTE6. FTE7. FTE8. BKGRD. [pmid: 12907089].
O'Connell MP, Gurney EM, Lindow SW. The philosophy of practice governs the rate of obstetric intervention: analysis of 212 units in the United Kingdom. J Matern Fetal Neonatal Med. 2003;13(4):267-70. Notes: KQ1 Search Journal Article. AI. FTE11. [pmid: 12854929].
Obara H, Minakami H, Koike T, Takamizawa S, Matsubara S, Sato I. Vaginal birth after cesarean delivery: results in 310 pregnancies. J Obstet Gynaecol Res. 1998;24(2):129-34. Notes: Outcomes Studies; Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 9631601].
Oboro VO, Dare FO, Ogunniyi SO. Outcome of term breech by intended mode of delivery. Niger J Med. 2004;13(2):106-9. Notes: Outcomes Studies; Journal Article. AI. FTE4. [pmid: 15293825].
Obwegeser R, Ulm M, Simon M, Ploeckinger B, Gruber W. Breech infants: vaginal or cesarean delivery?. Acta Obstet Gynecol Scand. 1996;75(10):912-6. Notes: Outcomes Studies; Journal Article. AI. FTE6. [pmid: 9003092].
Ohel G, Yaacobi N, Linder N, Younis J. Postdate antenatal testing. Int J Gynaecol Obstet. 1995;49(2):145-7. Notes: Harms Search; Journal Article. AI. FTE6. [pmid: 7649318].
Otamiri G, Berg G, Ledin T, Leijon I, Nilsson B. Influence of elective cesarean section and breech delivery on neonatal neurological condition. Early Hum Dev. 1990;23(1):53-66. Notes: infant and c-section additions. AI. FTE6. FTE8. [pmid: 2209475].
Palacios-Jaraquemada JM. Re: Placenta percreta with bladder invasion as a cause of life threatening hemorrhage. J Urol. 2001;166(1):220. Notes: CommentLetter Placenta Previa Search. AI. FTE3. FTE6. [pmid: 11435872].
Pallarito K. Study backs longer hospital stays for moms, infants after C-sections. Mod Healthc. 1995;25(33):16. Notes: infant and c-section additions. AI. FTE3. FTE6.
Parazzini F, Chiaffarino F, Lavezzari M, Giambanco V. Risk factors for stress, urge or mixed urinary incontinence in Italy. Br J Obstet Gynaecol. 2003;110(10):927-33. Notes: Urinary Incontinence Search; VIVA Study Group.Journal Article. AI. FTE6. BKGRD.
Parilla BV, Dooley SL, Jansen RD, Socol ML. Iatrogenic respiratory distress syndrome following elective repeat cesarean delivery. Obstet Gynecol. 1993;81(3):392-5. Notes: Harms Search; Journal Article. AI. FTE6. FTE8. [pmid: 8437793].
Parry E, Parry D, Pattison N. Induction of labour for post term pregnancy: an observational study. Aust N Z J Obstet Gynaecol. 1998;38(3):275-80. Notes: Outcomes Studies; Journal Article. AI. FTE6. FTE5. [pmid: 9761152].
Paterson CM, Saunders NJ. Mode of delivery after one caesarean section: audit of current practice in a health region. Br Med J. 1991;303(6806):818-21. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 1932972]. [pmcid: 1671146].
Peipert JF, Bracken MB. Maternal age: an independent risk factor for cesarean delivery. Obstet Gynecol. 1993;81(2):200-5. Notes: Outcomes Studies; Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 8423950].
Penna L, Arulkumaran S. Cesarean section for non-medical reasons. Int J Gynaecol Obstet. 2003;82(3):399-409. Notes: Harms Search; Journal Article. AI. FTE3. BKGRD. [pmid: 14499986].
Peschers UM, Sultan AH, Jundt K, Mayer A, Drinovac V, Dimpfl T. Urinary and anal incontinence after vacuum delivery. Eur J Obstet Gynecol Reprod Biol. 2003;110(1):39-42. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 12932869].
Peyrat L, Haillot O, Bruyere F, Boutin JM, Bertrand P, Lanson Y. Prevalence and risk factors of urinary incontinence in young and middle-aged women. BJU Int. 2002;89(1):61-6. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 11849162].
Pollina J, Dias MS, Li V, Kachurek D, Arbesman M. Cranial birth injuries in term newborn infants. Pediatr Neurosurg. 2001;35(3):113-9. Notes: Harms Search; Journal Article. AI. FTE6. [pmid: 11641618].
Pregazzi R, Sartore A, Troiano L, et al. Postpartum urinary symptoms: prevalence and risk factors. Eur J Obstet Gynecol Reprod Biol. 2002;103(2):179-82. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 12069744].
Prysak M, Castronova FC. Elective induction versus spontaneous labor: a case-control analysis of safety and efficacy. Obstet Gynecol. 1998;92(1):47-52. Notes: Harms Search; Clinical TrialJournal Article. AI. FTE6. DA. [pmid: 9649091].
Rageth JC, Juzi C, Grossenbacher H. Delivery after previous cesarean: a risk evaluation. Swiss Working Group of Obstetric and Gynecologic Institutions. Obstet Gynecol. 1999;93(3):332-7. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 10074973].
Randolph AG, Washington AE, Prober CG. Cesarean delivery for women presenting with genital herpes lesions. Efficacy, risks, and costs. J Am Med Assoc. 1993;270(1):77-82. Notes: infant and c-section additions. AI. FTE3. FTE6. FTE7.
Read JS, Tuomala R, Kpamegan E, et al. Mode of delivery and postpartum morbidity among HIV-infected women: the women and infants transmission study. J Acquir Immune Defic Syndr. 2001;26(3):236-45. Notes: infant and c-section additions. AI. FTE5. FTE6. [pmid: 11242196].
Richardson BS, Czikk MJ, daSilva O, Natale R. The impact of labor at term on measures of neonatal outcome. Am J Obstet Gynecol. 2005;192(1):219-26. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. [pmid: 15672028].
Rietberg CC, Elferink-Stinkens PM, Brand R, van Loon AJ, Van Hemel OJ, Visser GH. Term breech presentation in The Netherlands from 1995 to 1999: mortality and morbidity in relation to the mode of delivery of 33824 infants. Br J Obstet Gynaecol. 2003;110(6):604-9. Notes: Harms Search; Journal Article. AI. FTE6.
Rietberg CC, Elferink-Stinkens PM, Visser GH. The effect of the Term Breech Trial on medical intervention behaviour and neonatal outcome in The Netherlands: an analysis of 35,453 term breech infants. Br J Obstet Gynaecol. 2005;112(2):205-9. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. BKGRD.
Roberts CL, Peat B, Algert CS, Henderson-Smart D. Term breech birth in New South Wales, 1990-1997. Aust N Z J Obstet Gynaecol. 2000;40(1):23-9. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 10870774].
Robertson PA, Laros RK Jr, Zhao RL. Neonatal and maternal outcome in low-pelvic and midpelvic operative deliveries. Am J Obstet Gynecol. 1990;162(6):1436-42. discussion 1442–4. Notes: infant and c-section additions. AI. FTE6. DA. [pmid: 2360576].
Rode L, Nilas L, Wojdemann K, Tabor A. Obesity-related complications in Danish single cephalic term pregnancies. Obstet Gynecol. 2005;105(3):537-42. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE6. [pmid: 15738021].
Rortveit G, Daltveit AK, Hannestad YS, Hunskaar S. Urinary incontinence after vaginal delivery or cesarean section. N Engl J Med. 2003;348(10):900-7. Notes: Urinary Incontinence Search; Norwegian EPINCONT Study.Journal Article. AI. FTE6. [pmid: 12621134].
Rortveit G, Daltveit AK, Hannestad YS, Hunskaar S. Vaginal delivery parameters and urinary incontinence: the Norwegian EPINCONT study. Am J Obstet Gynecol. 2003;189(5):1268-74. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 14634552].
Rosen MG, Dickinson JC, Westhoff CL. Vaginal birth after cesarean: a meta-analysis of morbidity and mortality. Obstet Gynecol. 1991;77(3):465-70. Notes: Meta-analysis Search; KQ1 Search Journal ArticleMeta-Analysis. AI. FTE3. [pmid: 1825136].
Rosenthal AR. Elective caesarean section on request. Maternal age is important. Br Med J. 1999;318(7176):121-2. Notes: Harms Search; CommentLetter. AI. FTE3. FTE6. FTE5. FTE7. FTE8. BKGRD. [pmid: 10068232].
Roth-Kleiner M, Wagner BP, Bachmann D, Pfenninger J. Respiratory distress syndrome in near-term babies after caesarean section. Swiss Med Wkly. 2003;133(1920):283-8. Notes: Harms Search; Journal Article. AI. FTE6. FTE8. BKGRD. [pmid: 12844271].
Rouse DJ, Landon M, Leveno KJ, et al. The Maternal-Fetal Medicine Units cesarean registry: chorioamnionitis at term and its duration-relationship to outcomes. Am J Obstet Gynecol. 2004;191(1):211-6. Notes: infant and c-section additions. AI. FTE6. [pmid: 15295368].
Rout CC, Rocke D, Levin J, Gouws E, Reddy D. A reevaluation of the role of crystalloid preload in the prevention of hypotension associated with spinal anesthesia for elective cesarean section. Anesthesiology. 1993;79(2):262-9. Notes: Cochrane CCTR Search; EMBASE Search;Label: PBS Record: 570. AI. FTE4. FTE6. [pmid: 8192733].
Rouzi AA, Khalifa F, Ba'aqeel H, Al-Hamdan HS, Bondagji N. The routine use of cefazolin in cesarean section. Int J Gynaecol Obstet. 2000;69(2):107-12. Notes: Harms Search; RCT Search; Clinical TrialJournal ArticleRandomized Controlled Trial. AI. FTE4. [pmid: 10802077].
Rozenberg P, Goffinet F, Philippe HJ, Nisand I. Thickness of the lower uterine segment: its influence in the management of patients with previous cesarean sections. Eur J Obstet Gynecol Reprod Biol. 1999;87(1):39-45. Notes: Harms Search; Journal Article. AI. FTE6. [pmid: 10579615].
Ryan CA, Hughes P. Neonatal respiratory morbidity and mode of delivery at term: influence of timing of elective caesarean section. Br J Obstet Gynaecol. 1995;102(10):843-4. Notes: Harms Search; CommentLetter. AI. FTE3. FTE4. FTE5. FTE6. FTE7. FTE8. BKGRD. [pmid: 7547751].
Rydhstrom H, Ingemarsson I. No benefit from conservative management in nulliparous women with premature rupture of the membranes (PROM) at term. A randomized study. Acta Obstet Gynecol Scand. 1991;70(78):543-7. Notes: Neonate outcome study Clinical TrialJournal ArticleRandomized Controlled Trial. AI. FTE6. [pmid: 1785268].
Ryhammer AM, Bek KM, Laurberg S. Multiple vaginal deliveries increase the risk of permanent incontinence of flatus urine in normal premenopausal women. Dis Colon Rectum. 1995;38(11):1206-9. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 7587765].
Sabrine N. Caesarean section controversy. Elective caesarean can increase the risk to the fetus. Br Med J. 2000;320(7241):1073-4. Notes: Harms Search; CommentLetter. AI. FTE6. [pmid: 10836806].
Sadler LC, Davison T, McCowan LM. A randomised controlled trial and meta-analysis of active management of labour. Br J Obstet Gynaecol. 2000;107(7):909-15. Notes: Neonate outcome study Clinical TrialJournal ArticleMeta-AnalysisRandomized Controlled Trial. AI. FTE6.
Sagadyleslie M. Counseling women about elective cesarean section. J Midwifery Womens Health. 2004;49(2):155-9. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE3. BKGRD. [pmid: 15010671].
Saleh SS. The changing trend in the rate of caesarean section at a teaching hospital. J Obstet Gynaecol. 2003;23(2):146-9. Notes: KQ1 Search Journal Article. AI. FTE4. [pmid: 12745557].
Salihu HM, Li Q, Rouse DJ, Alexander GR. Placenta previa: neonatal death after live births in the United States. Am J Obstet Gynecol. 2003;188(5):1305-9. Notes: Journal Article Placenta Previa Search. AI. FTE6. [pmid: 12748503].
Sangalli M, Guidera A. Caesarean section in term nulliparous women at Wellington Hospital in 2001: a regional audit. N Z Med J. 2004;117(1206):U1184. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 15570353].
Sartore A, DeSeta F, Maso G, Pregazzi R, Grimaldi E, Guaschino S. The effects of mediolateral episiotomy on pelvic floor function after vaginal delivery. Obstet Gynecol. 2004;103(4):669-73. Notes: Urinary Incontinence Search; Clinical TrialControlled Clinical TrialJournal Article. AI. FTE6. [pmid: 15051557].
Sartore A, Pregazzi R, Bortoli P, Grimaldi E, Ricci G, Guaschino S. The urine stream interruption test and pelvic muscle function in the puerperium. Int J Gynaecol Obstet. 2002;78(3):235-9. Notes: Urinary Incontinence Search; Evaluation StudiesJournal Article. AI. FTE6. [pmid: 12384269].
Schiff E, Friedman SA, Mashiach S, Hart O, Barkai G, Sibai BM. Maternal and neonatal outcome of 846 term singleton breech deliveries: seven-year experience at a single center. Am J Obstet Gynecol. 1996;175(1):18-23. Notes: Comparison Studies Journal Article. AI. FTE6. [pmid: 8694048].
Seffah JD. Maternal and perinatal mortality and morbidity associated with transverse lie. Int J Gynaecol Obstet. 1999;65(1):11-5. Notes: Outcomes Studies; Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 10390094].
Seidman DS, Laor A, Gale R, Stevenson DK, Mashiach S, Danon YL. Long-term effects of vacuum and forceps deliveries. Lancet. 1991;337(8757):1583-5. Notes: infant and c-section additions. AI. FTE6. [pmid: 1675719].
Seidman DS, Paz I, Nadu A, et al. Are multiple cesarean sections safe?. Eur J Obstet Gynecol Reprod Biol. 1994;57(1):7-12. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE6. [pmid: 7821507].
Semprini AE, Castagna C, Ravizza M, et al. The incidence of complications after caesarean section in 156 HIV-positive women. AIDS. 1995;9(8):913-7. Notes: infant and c-section additions. AI. FTE5. FTE6. [pmid: 7576327].
Sepilian V, Perni S, Ameri V, Forouzan I. The effect of placental delivery method during elective cesarean delivery on blood loss and endometritis. Obstet Gynecol. 2003;101(4 Suppl):8S-9S. Notes: Cochrane CCTR Search; EMBASE Search;Label: PBS Record: 20. AI. FTE3.
Shaver DC, Bada HS, Korones SB, Anderson GD, Wong SP, Arheart KL. Early and late intraventricular hemorrhage: the role of obstetric factors. Obstet Gynecol. 1992;80(5):831-7. Notes: infant and c-section additions. AI. FTE5. FTE6. FTE8. [pmid: 1407923].
Sheiner E, Levy A, Katz M, Mazor M. Pregnancy outcome following recurrent spontaneous abortions. Eur J Obstet Gynecol Reprod Biol. 2005;118(1):61-5. Notes: Journal Article Placenta Previa Search. AI. FTE6. [pmid: 15596274].
Sheiner E, Segal D, Shoham-Vardi I, BenTov J, Katz M, Mazor M. The impact of early amniotomy on mode of delivery and pregnancy outcome. Arch Gynecol Obstet. 2000;264(2):63-7. Notes: Comparison Studies Journal Article. AI. FTE6. [pmid: 11045324].
Sheiner E, ShohamVardi I, Hershkovitz R, Katz M, Mazor M. Infertility treatment is an independent risk factor for cesarean section among nulliparous women aged 40 and above. Am J Obstet Gynecol. 2001;185(4):888-92. Notes: Comparison Studies Journal Article. AI. FTE6. BKGRD. [pmid: 11641672].
Shen JJ, Tymkow C, MacMullen N. Disparities in maternal outcomes among four ethnic populations. Ethn Dis. 2005;15(3):492-7. Notes: PREVIA UPDATE. AI. FTE. [pmid: 16108310].
Shorten A, Lewis DE, Shorten B. Trial of labour versus elective repeat caesarean section: a cost-effectiveness analysis. Aust Health Rev. 1998;21(1):8-28. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. FTE3. DA. [pmid: 10181675].
Signorelli C, Cattaruzza MS, Osborn JF. Risk factors for caesarean section in Italy: results of a multicentre study. Public Health. 1995;109(3):191-9. Notes: Harms Search; KQ1 Search Journal ArticleMulticenter Study. AI. FTE6. [pmid: 7597132].
Silva AA, Barbieri MA, Gomes UA, Bettiol H. Trends in low birth weight: a comparison of two birth cohorts separated by a 15-year interval in Ribeirao Preto, Brazil. Bull World Health Organ. 1998;76(1):73-84. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE6. [pmid: 9615499].
Silva AA, Lamy-Filho F, Alves MT, Coimbra LC, Bettiol H, Barbieri MA. Risk factors for low birthweight in north-east Brazil: the role of caesarean section. Paediatr Perinat Epidemiol. 2001;15(3):257-64. Notes: Outcomes Studies; Harms Search; KQ1 Search Journal ArticleMulticenter Study. AI. FTE6. [pmid: 11489154].
Skoner MM, Thompson WD, Caron VA. Factors associated with risk of stress urinary incontinence in women. Nurs Res. 1994;43(5):301-6. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 7937177].
Smith GC. A population study of birthweight and the risk of caesarean section: Scotland 1980-1996. Br J Obstet Gynaecol. 2000;107(6):740-4. Notes: Harms Search; KQ1 Search Journal Article. AI. FTE6. BKGRD.
Smith GC, Pell JP, Dobbie R. Caesarean section and risk of unexplained stillbirth in subsequent pregnancy. Lancet. 2003;362(9398):1779-84. Notes: infant and c-section additions. AI. FTE6. [pmid: 14654315].
Smith JF, Hernandez C, Wax JR. Fetal laceration injury at cesarean delivery. Obstet Gynecol. 1997;90(3):344-6. Notes: HAND SEARCH. AI. FTE6. BKGRD. [pmid: 9277641].
Spaans WA, van der Vliet LM, Roell-Schorer EA, Bleker OP, van Roosmalen J. Trial of labour after two or three previous caesarean sections. Eur J Obstet Gynecol Reprod Biol. 2003;110(1):16-9. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 12932864].
Sperling LS, Henriksen TB, Ulrichsen H, et al. Indications for cesarean section in singleton pregnancies in two Danish counties with different cesarean section rates. Acta Obstet Gynecol Scand. 1994;73(2):129-35. Notes: Comparison Studies Journal Article. AI. FTE6. [pmid: 8116351].
Stanco LM, Schrimmer DB, Paul RH, Mishell DR Jr. Emergency peripartum hysterectomy and associated risk factors. Am J Obstet Gynecol. 1993;168(3 Pt 1):879-83. Notes: Journal Article Placenta Previa Search. AI. FTE6. [pmid: 8456896].
Su M, Hannah WJ, Willan A, Ross S, Hannah ME. Planned caesarean section decreases the risk of adverse perinatal outcome due to both labour and delivery complications in the Term Breech Trial. Br J Obstet Gynaecol. 2004;111(10):1065-74. Notes: Harms Search; RCT Search; Term Breech Trial collaborative group.Clinical TrialJournal ArticleMulticenter StudyRandomized Controlled Trial. AI. FTE6.
Su M, McLeod L, Ross S, et al. Factors associated with adverse perinatal outcome in the Term Breech Trial. Am J Obstet Gynecol. 2003;189(3):740-5. Notes: Outcomes Studies; Harms Search; Term Breech Trial Collaborative Group.Journal Article. AI. FTE6. [pmid: 14526305].
Sue-A-Quan AK, Hannah ME, Cohen MM, Foster GA, Liston RM. Effect of labour induction on rates of stillbirth and cesarean section in post-term pregnancies. Can Med Assoc J. 1999;160(8):1145-9. Notes: Outcomes Studies; Harms Search; Meta-analysis Search; KQ1 Search Journal ArticleMeta-Analysis. AI. FTE5. FTE6. [pmid: 10234344]. [pmcid: 1230266].
Sultan AH, Kamm MA, Hudson CN. Pudendal nerve damage during labour: prospective study before and after childbirth. Br J Obstet Gynaecol. 1994;101(1):22-8. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE6. [pmid: 8297863].
Sultan AH, Monga AK, Stanton SL. The pelvic floor sequelae of childbirth. Br J Hosp Med. 1996;55(9):575-9. Notes: Urinary Incontinence Search; Journal ArticleReview. AI. FTE3. BKGRD. [pmid: 8735035].
Swaim LS, Holste CS, Waller DK. Umbilical cord blood pH after prior cesarean delivery. Obstet Gynecol. 1998;92(3):390-3. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 9721776].
Taffel SM. Cesarean delivery in the United States, 1990. Vital Health Stat 21 1994; (51):1–24. Notes: infant and c-section additions AI FTE11
Tan YY, Yeo GS. Impaired glucose tolerance in pregnancy—is it of consequence?. Aust N Z J Obstet Gynaecol. 1996;36(3):248-55. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE4. [pmid: 8883744].
Tanbo T, Dale PO, Lunde O, Moe N, Abyholm T. Obstetric outcome in singleton pregnancies after assisted reproduction. Obstet Gynecol. 1995;86(2):188-92. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE6. [pmid: 7617348].
Taylor GM. An audit of the implementation of guidelines to reduce wound infection following caesarean section. Health Bull (Edinb). 2000;58(1):38-44. Notes: Harms Search; Journal Article. AI. FTE6. [pmid: 12813851].
Taylor VM, Kramer MD, Vaughan TL, Peacock S. Placenta previa and prior cesarean delivery: how strong is the association?. Obstet Gynecol. 1994;84(1):55-7. Notes: Journal Article Placenta Previa Search. AI. FTE6. [pmid: 8008323].
Tetzschner T, Sorensen M, Jonsson L, Lose G, Christiansen J. Delivery and pudendal nerve function. Acta Obstet Gynecol Scand. 1997;76(4):324-31. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 9174425].
Thomas L, Ptak H, Giddings LS, Moore L, Oppermann C. The effects of rocking, diet modifications, and antiflatulent medication on postcesarean section gas pain. J Perinat Neonatal Nurs. 1990;4(3):12-24. Notes: infant and c-section additions. AI. FTE6. [pmid: 2243324].
Thompson JF, Roberts CL, Currie M, Ellwood DA. Prevalence and persistence of health problems after childbirth: associations with parity and method of birth. Birth. 2002;29(2):83-94. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 12051189].
Thorpe-Beeston JG, Banfield PJ, Saunders NJ. Outcome of breech delivery at term. Br Med J. 1992;305(6856):746-7. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. [pmid: 1422330]. [pmcid: 1883401].
To WW, Leung WC. Placenta previa and previous cesarean section. Int J Gynaecol Obstet. 1995;51(1):25-31. Notes: Journal Article Placenta Previa Search. AI. FTE4. [pmid: 8582514].
Toepke M. Marion's message. Power and intervention. Midwifery Today Int Midwife 2002; (63):7, 60. Notes: infant and c-section additions AI FTE10
Tranquilli AL, Giannubilo SR. Cesarean delivery on maternal request in Italy. Int J Gynaecol Obstet. 2004;84(2):169-70. Notes: KQ1 Search Journal Article. AI. FTE6. [pmid: 14871522].
Turnquest MA, James T, Marcell C, Spinnato JA. Vaginal birth after cesarean section in a university setting. J Ky Med Assoc. 1994;92(6):216-21. Notes: infant and c-section additions. AI. FTE6. [pmid: 8051495].
Udy P. Elective cesarean: a betrayal of trust. Midwifery Today Int Midwife 2002; (63):35–6. Notes: Harms Search; Journal Article AI FTE3 FTE4 FTE5 FTE6 FTE7 FTE8
Unger JB, Meeks GR. Vaginal hysterectomy in women with history of previous cesarean delivery. Am J Obstet Gynecol. 1998;179(6 Pt 1):1473-8. Notes: Comparison Studies Journal Article. AI. FTE6. [pmid: 9855583].
Vallejo MC, Mandell GL, Sabo DP, Ramanathan S. Postdural puncture headache: a randomized comparison of five spinal needles in obstetric patients. Anesth Analg. 2000;91(4):916-20. Notes: RCT Search; Clinical TrialJournal ArticleRandomized Controlled Trial. AI. FTE6. [pmid: 11004048].
van Roosmalen J, van der Does CD. Caesarean birth rates worldwide. A search for determinants. Trop Geogr Med. 1995;47(1):19-22. Notes: Harms Search; Journal Article. AI. FTE3. BKGRD. [pmid: 7747325].
Videla FL, Satin AJ, Barth WH Jr, Hankins GD. Trial of labor: a disciplined approach to labor management resulting in a high rate of vaginal delivery. Am J Perinatol. 1995;12(3):181-4. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE6. [pmid: 7612091].
Viktrup L, Lose G. Do fertile women remember the onset of stress incontinence? Recall bias 5 years after 1st delivery. Acta Obstet Gynecol Scand. 2001;80(10):952-5. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 11580741].
Viktrup L, Lose G. The risk of stress incontinence 5 years after first delivery. Am J Obstet Gynecol. 2001;185(1):82-7. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 11483909].
Viktrup L, Lose G, Rolff M, Barfoed K. The symptom of stress incontinence caused by pregnancy or delivery in primiparas. Obstet Gynecol. 1992;79(6):945-9. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 1579319].
Volmink J. Mother to child transmission of HIV. Clin Evid 2002; (7):709–16. Notes: Neonate outcome study Journal Article Review AI FTE3 FTE6
Wagenius J, Laurin J. Clinical symptoms after anal sphincter rupture: a retrospective study. Acta Obstet Gynecol Scand. 2003;82(3):246-50. Notes: Urinary Incontinence Search; Journal Article. AI. FTE6. [pmid: 12694121].
Wahab MA, Karantzis P, Eccersley PS, Russell IF, Thompson JW, Lindow SW. A randomised, controlled study of uterine exteriorisation and repair at caesarean section. Br J Obstet Gynaecol. 1999;106(9):913-6. Notes: Harms Search; Clinical TrialJournal ArticleRandomized Controlled Trial. AI. FTE6. [pmid: 10492101].
Wall LL. Cost-effectiveness of elective cesarean delivery after one prior low transverse cesarean. Obstet Gynecol. 2000;96(3):482. Notes: Urinary Incontinence Search; Harms Search; CommentLetter. AI. FTE3. FTE6. FTE4. FTE5. FTE7. FTE8. BKGRD. [pmid: 11001700].
Watts DH, Lambert JS, Stiehm ER, et al. Complications according to mode of delivery among human immunodeficiency virus-infected women with CD4 lymphocyte counts of < or = 500/microL. Am J Obstet Gynecol. 2000;183(1):100-7. Notes: RCT Search; Clinical TrialJournal ArticleRandomized Controlled Trial. AI. FTE5. FTE6. [pmid: 10920316].
Wax JR, Herson V, Carignan E, Mather J, Ingardia CJ. Contribution of elective delivery to severe respiratory distress at term. Am J Perinatol. 2002;19(2):81-6. Notes: Harms Search; Journal Article. AI. FTE6. FTE8. BKGRD. [pmid: 11938481].
Webb RJ, Kantor GS. Obstetrical epidural anaesthesia in a rural Canadian hospital. Can J Anaesth. 1992;39(4):390-3. Notes: KQ1 Search Journal Article. AI. FTE6. DA. [pmid: 1563063].
Weeks S. Reflections on hypotension during Cesarean section under spinal anesthesia: do we need to use colloid?. Can J Anaesth. 2000;47(7):607-10. Notes: infant and c-section additions. AI. FTE3. FTE6. FTE7. [pmid: 10930197].
Weiss PM, Balducci J, Reed J, Klasko SK, Rust OA. Does centralized monitoring affect perinatal outcome?. J Matern Fetal Med. 1997;6(6):317-9. Notes: Outcomes Studies; Journal Article. AI. FTE6. [pmid: 9438212].
Wen SW, Demissie K, Liu S, Marcoux S, Kramer MS. Placenta praevia and male sex at birth: results from a population-based study. Paediatr Perinat Epidemiol. 2000;14(4):300-4. Notes: Journal Article Placenta Previa Search. AE. FTE12. [pmid: 11101015].
Wen SW, Rusen ID, Walker M, et al. Comparison of maternal mortality and morbidity between trial of labor and elective cesarean section among women with previous cesarean delivery. Am J Obstet Gynecol. 2004;191(4):1263-9. Notes: Harms Search; KQ1 Search Maternal Health Study Group, Canadian Perinatal Surveillance System.Journal Article. AI. FTE6. [pmid: 15507951].
White JJ. Outcome analysis for gastroschisis. J Pediatr Surg. 2000;35(2):398-9. Notes: Outcomes Studies; CommentLetter. AI. FTE3. FTE6. BKGRD. [pmid: 10693705].
Whyte H, Hannah ME, Saigal S, et al. Outcomes of children at 2 years after planned cesarean birth versus planned vaginal birth for breech presentation at term: the International Randomized Term Breech Trial. Am J Obstet Gynecol. 2004;191(3):864-71. Notes: Cochrane CCTR Search; Harms Search; RCT Search; Term Breech Trial Collaborative Group.Clinical TrialJournal ArticleRandomized Controlled Trial. AI. FTE6. [pmid: 15467555].
Wong J, Gatt S. Combined spinal epidural versus epidural anesthesia for elective cesarean section. Anesthesiology. 1999;90(4 Suppl):A72. Notes: (42) EMBASE Search;Label: PBS Record: 270. AI. FTE6. FTE8. [pmid: 9915315].
Wood RM, Simon H, Oz AU. Pelosi-type vs. traditional cesarean delivery. A prospective comparison. J Reprod Med. 1999;44(9):788-95. Notes: Comparison Studies Journal Article. AI. FTE6. [pmid: 10509303].
Wu JM, Hundley AF, Visco AG. Elective primary cesarean delivery: attitudes of urogynecology and maternal-fetal medicine specialists. Obstet Gynecol. 2005;105(2):301-6. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE5. FTE6. [pmid: 15684156].
Wu S, Kocherginsky M, Hibbard JU. Abnormal placentation: twenty-year analysis. Am J Obstet Gynecol. 2005;192(5):1458-61. Notes: Journal Article Placenta Previa Search. AE. FTE6. [pmid: 15902137].
Wu Y, Zhan L, Jing Y. Prevention of post-operative infection by uterine and intraperitoneal irrigation with ampicillin during cesarean section. Int J Exp Clin Chemother. 1991;4(3):132-6. Notes: (42) EMBASE Search; Label: PBS Record: 600. AI. FTE4.
Yaegashi N, Chiba-Sekii A, Okamura K. Emergency postpartum hysterectomy in women with placenta previa and prior cesarean section. Int J Gynaecol Obstet. 2000;68(1):49-52. Notes: PREVIA UPDATE. AI. FTE. [pmid: 10687838].
Yamani Zamzami TY. Indication of emergency peripartum hysterectomy: review of 17 cases. Arch Gynecol Obstet. 2003;268(3):131-5. Notes: PREVIA UPDATE. AI. FTE. [pmid: 12756583].
Yan JS, Chang YK, Yin CS. Elective cesarean section for macrosomia?. Zhonghua Yi Xue Za Zhi (Taipei). 1994;53(3):141-5. Notes: Outcomes Studies; KQ1 Search Journal Article. AI. FTE4. FTE6. [pmid: 8174008].
Yancey MK, Pierce B, Schweitzer D, Daniels D. Observations on labor epidural analgesia and operative delivery rates. Am J Obstet Gynecol. 1999;180(2 Pt 1):353-9. Notes: Outcomes Studies; Journal Article. AI. FTE6. [pmid: 9988800].
Yang JY, Fang LJ, Tsou YauKI. Labor pain before elective cesarean section reduces neonatal respiratory distress. Zhonghua Min Guo Xiao Er Ke Yi Xue Hui Za Zhi. 1997;38(1):38-43. Notes: Harms Search; Journal Article. AI. FTE4. [pmid: 9066188].
Yawn BP, Wollan P, McKeon K, Field CS. Temporal changes in rates and reasons for medical induction of term labor, 1980-1996. Am J Obstet Gynecol. 2001;184(4):611-9. Notes: KQ1 SearchJournal Article. AI. FTE6. [pmid: 11262461].
Yeast JD, Jones A, Poskin M. Induction of labor and the relationship to cesarean delivery: A review of 7001 consecutive inductions. Am J Obstet Gynecol. 1999;180(3 Pt 1):628-33. Notes: Outcomes Studies; Harms Search; KQ1 SearchJournal Article. AI. FTE6. [pmid: 10076139].
Yip SK, Sahota D, Chang A, Chung T. Effect of one interval vaginal delivery on the prevalence of stress urinary incontinence: a prospective cohort study. Neurourol Urodyn. 2003;22(6):558-62. Notes: Urinary Incontinence Search; Journal Article. AI. FTE4. FTE6. [pmid: 12951663].
Young D. Confrontation in Kansas City: elective cesareans and maternal choice. Birth. 2000;27(3):153-5. Notes: Harms Search; CommentEditorial. AI. FTE3. FTE5. FTE6. FTE7. FTE4. FTE8. BKGRD. [pmid: 11251495].
Zaki ZM, Bahar AM, Ali ME, Albar HA, Gerais MA. Risk factors and morbidity in patients with placenta previa accreta compared to placenta previa non-accreta. Acta Obstet Gynecol Scand. 1998;77(4):391-4. Notes: Journal Article Placenta Previa Search. AI. FTE4. FTE6. [pmid: 9598946].
Zamorski MA, Biggs WS. Management of suspected fetal macrosomia. Am Fam Physician. 2001;63(2):302-6. Notes: Harms Search; Journal Article. AI. FTE6. [pmid: 11201695].
Zanardo V, Simbi AK, Savio V, Micaglio M, Trevisanuto D. Neonatal resuscitation by laryngeal mask airway after elective cesarean section. Fetal Diagn Ther. 2004;19(3):228-31. Notes: Harms Search; Journal Article. AI. FTE6. [pmid: 15067232].
Zhang J, Savitz DA. Maternal age and placenta previa: a population-based, case-control study. Am J Obstet Gynecol. 1993;168(2):641-5. Notes: Journal Article Placenta Previa Search. AI. FTE6. [pmid: 8438945].
Zhang J, Yancey MK, Klebanoff MA, Schwarz J, Schweitzer D. Does epidural analgesia prolong labor and increase risk of cesarean delivery? A natural experiment. Am J Obstet Gynecol. 2001;185(1):128-34. Notes: Outcomes Studies; Harms Search; Journal Article. AI. FTE6. [pmid: 11483916].