# Appendix C: Evidence Table

Glossary

BMI | body mass index
BPD | biparetal diameter
c/d | cesarean delivery
CES-D | Center for Epidemiologic Studies - Depression Scale
cm | centimeters
CPD | cephalopelvic disproportion
CT | computer tomography
d | day
Dec | December
Dept | department
EFW | estimated fetal weight
Feb | February
F/U | follow-up
G | group
GA | gestational age
gms | grams
HELLP | Hemolysis Elevated Liver Enzymes and Low Platelet Count
Hr(s) | hour(s)
HSV | herpes simpleton virus
HTN | hypertension
hx | history
IQ | intraquartile
IUGR | intrauterine growth restriction
Jan | January
kg | kilograms
LMP | last menstrual period
Ml | milliliter
mm | millimeter
mos | months
multip | multiparous
N | number
NICU | Neonatal Intensive Care Unit
NR | not reported
Ob/Gyn | obstetrics/gynecology
OR | odds ratio
P | probability
post-op | post operative
PP | postpartum
PPH | persistent pulmonary hypterension
primp | primiparous
PROM | premature rupture of membranes
RCT | randomized controlled trial
RDS | Respiratory Distress Syndrome
RR | relative risk
SD | standard deviation
Sept | September
SUI | stress urinary incontinence
TTN | transient tachypnea of the newborn
UK | United Kingdom
u/s | ultrasonography
US | United States
VAS | Visual Analog Scale
VD | vaginal delivery
vs | versus
wks | weeks
w/o | without
w/in | within
yr(s) | year(s)

Evidence Table 1. Maternal outcomes of cesarean delivery on maternal request

Evidence Table 1. Maternal outcomes of cesarean delivery on maternal request

Study characteristics | Objective and definitions | Labor and delivery characteristics | Short Term Maternal Outcomes | Long term Maternal Outcomes | Relevance and Quality Ratings
Author | Objective of the study | Maternal age, mean ± SD | Wound infection, N (%) | NR | Relevance
Allen et al., 2003 | To estimate the maternal morbidity associated with cesarean deliveries performed at term without labor compared with morbidity associated with spontaneous labor | G1: 27.3 (5.3) | G1: 11/721 (1.5) | | Low
Setting | Definition of elective cesarean | G2: 25.3 (5.1) | G2A: 55/12,607 (0.4) | | Quality Rating
Canada, Population-based | The term “elective” is not used at all. Referent group is cesarean (planned and unplanned) without labor for maternal and neonatal indications | P < 0.001 | RR = 3.5 (1.8, 6.7) | | Not rated
Study design | Category includes:; - Breech (86%); - Fetal distress (4.2%); - Dystocia (5.1%); - Malpresentation (1.1%); - Maternal HSV (0.4%); - Others (2.6%); - Diseases of the cervix (0.1%) | Maternal weight at delivery in kgs ± SD | P < 0.001
Retrospective cohort | | G1: 81.6 (15.2) | G2b: 70/3,613 (2.0)
Inclusion criteria | | G2: 78.5 (12.9) | RR = 0.8 (0.4, 1.5)
- Pregnancies to Novia Scotia resident, ≥ 500 grm birthweight; - Between 1/1/88 and 12/31/01; - Liveborn singleton at term (37 to 42 wks); - Born to a nulliparous woman | | P < 0.001 | G2c: 32/1,480 (2.2)
Exclusion criteria | | Gravidity | RR = 0.7 (0.4, 1.4)
- Major fetal anomaly; - Labor induced; - Nonvertex presentation with spontaneous labor; - Preexisting maternal disease; - Fetal growth restriction ( < 10th percentile for GA); - Pregnancy complications (i.e., gestational diabetes pregnancy induced HTN, premature rupture of membranes) | | All nulliparous | Blood transfusions, N (%)
Groups | | N of previous cesareans | G1: 2/721 (0.3)
G1: c/d without labor | | NA | G2a: 38/12,607 (0.3)
G2: Spontaneous onset of labor:; - G2a: Spontaneous vaginal delivery; - G2b: Assisted vaginal delivery; - G2c: c/d in labor | | Diabetes | RR = 0.9 (0.2, 3.8)
| | None, all excluded | G2b: 27/3,613 (0.8)
| | Gestational age in wks ± SD | RR = 0.4 (0.1, 1.6)
| | G1: 39.3 ± 1.2 | G2c: 8/1,480 (0.5)
| | G2: 39.8 ± 1.2 | RR = 0.5 (0.1, 2.4)
| | P < 0.001 | Puerperal febrile morbidity, N (%)
| | Type of labor | G1: 8/721 (1.1)
| | NR | G2a: 26/12,607 (0.2)
| | Type of anesthesia | RR = 5.4 (2.4, 11.8)
| | NR | P < 0.001
| | Fetal weight | G2b: 14/3,613 (0.4)
| | NR | RR = 3.0 (1.2, 7.2)
| | | P < 0.05
| | | G2c: 49/1,480 (3.3)
| | | RR = 0.3 (0.2, 0.7)
| | | P < 0.05
| | | Evacuation of hematoma, N (%)
| | | G1: 1/721 (0.1)
| | | G2a: 18/12,607 (0.1)
| | | RR = 1.0 (0.1, 7.3)
| | | G2b: 3/3,613 (0.1)
| | | RR = 1.7 (0.2, 16.0)
| | | G2c: 3/1,480 (0.2)
| | | RR = 0.7 (0.1, 6.6)
| | | Early PPH (PP hemorrhage), N (%)
| | | G1: 28/721 (3.8)
| | | G2a: 640/12,607 (5.1)
| | | RR = 0.8 (0.5, 1.1)
| | | G2b: 346/3,613 (9.6)
| | | RR = 0.4 (0.3, 0.6)
| | | P < 0.001
| | | G2c: 111/1,480 (7.5)
| | | RR = 0.5 (0.4, 0.8)
| | | P < 0.001
Author | Objective of the study | Maternal age ± SD | Lacerations, N (%) | Uterine rupture (all had previous cesareans, so outcome of previous cesarean), N (%) | Relevance
Bergholt et al., 2003 | To estimate the incidence of intraoperative surgical complications with the impact of the educational level of the surgeon and a history of previous cesarean delivery on intraoperative complications at cesarean childbirth | Overall: 30.3 ± 4.9 | Cervical laceration | G1: 3/636 (0.5) | Moderate
Setting | Definition of elective cesarean | Maternal BMI, pre-pregnancy, N | G1: 29/636 (4.6) | G2: 0/294 (0.0) | Quality rating
Denmark, hospital-based | An operation planned more than 8 hours before the operation actually took place | Overall: 23.3 ± 4.3 | G2: 4/294 (1.4) | NS | Fair
Study design | Includes labored births, number NR | Parity overall ± SD | P < 0.05
Retrospective cohort | Category includes:; - Fetal distress; - Dystocia; - Placental abruption; - Multiple gestation; - Fetal anomalous presentation | Overall: 0.7 ± 0.9 | Corporal laceration
Inclusion criteria | | N of previous cesareans, N (%) | G1: 2/636 (0.3)
- Women delivering by c/d at the University hospitals in Gentofte, Herlev and Glostrup | | Overall: 237/929 ± 25.7 | G2: 1/294 (0.3)
Exclusion criteria | | Diabetes | NS
- NR | | NR | Vaginal laceration
Groups | | Gestational age ± SD | G1: 11/636 (1.7)
G1: Emergency c/d (c/d planned less than 8 hrs before operation actually took place) | | Overall: 38.7 ± 2.7 | G2: 0/294 (0)
G2: Elective c/d (c/d planned more than 8 hrs before operation actually took place) | | Type of labor | P < 0.05
N | | NR | Bladder laceration
G1: 636 | | Type of anesthesia | G1: 5/636 (0.8)
G2: 294 | | NR | G2: 0/294 (0)
| | Fetal weight mean kgs ± SD | NS
| | Overall: 3.315 ± 0.799 | Bowel laceration
| | | G1: 0/636 (0)
| | | G2: 0/294 (0)
| | | NS
| | | All lacerations
| | | G1: 43/636 (0)
| | | G2: 5/294 (0)
| | | P < 0.05
| | | Blood transfusion, N (%)
| | | G1: 7/636 (1.1)
| | | G2: 2/294 (0.7)
| | | NS
| | | Estimated blood loss ≥ 1000ml, N (%)
| | | G1: 57/636 (9.0)
| | | G2: 20/294 (6.8)
| | | NS
| | | Hysterectomy, N (%)
| | | G1: 1/636 (0.2)
| | | G2: 1/294 (0.3)
| | | NS
| | | All intraoperative surgical complications, N (%)
| | | G1: 92/636 (14.5)
| | | G2: 20/294 (6.8)
| | | P < 0.001
| | | Risk of intraoperative laceration of the cervix, vagina, and bladder from emergency c/d
| | | Crude OR: 4.2
| | | Adj OR: 2.3 (0.8–6.7)
| | | Variables include educational level of surgeon, previous c/d, pre-pregnancy BMI, duration of regular painful contractions, placental abruption as indication, placenta previa as indication, birthweight
| | | Risk of intraoperative blood loss ≥ 1000 ml during the cesarean delivery from emergency c/d
| | | Crude OR: 1.3
| | | Adj OR: 1.6 (0.7–3.4)
| | | Variables include educational level of surgeon, previous c/d, pre-pregnancy BMI, duration of regular painful contractions, pacental abruption as indication, placenta previa as indication, birthweight
Author | Objective of the study | Maternal Age, mean yrs ± SD | Endometritis, N (%) | NR | Relevance
Burrows, Meyn, Weber 2004 | To describe postpartum maternal morbidity associated with mode of delivery in term, singleton pregnancies | G1: 28.7 ± 6.0 | G1: 97 (0.4) | | Moderate
Setting | Definition of elective cesarean | G2: 28.4 ± 6.1 | G2: 33 (0.7) | | Quality Ratings
US, Hospital | NR | G3: 30.4 ± 6.0 | G3: 20 (3.0) | | Fair
Study design | | G4: 29.2 ± 6.0 | G4: 315 (9.4)
Retrospective-cohort | | G5: 32.3 ± 4.8 | G5: 35 (4.6)
Inclusion criteria | | G6: 32.7± 4.8 | G6: 23 (2.7)
- Singleton pregnancies at term (≥37 weeks); - One or no deliveries at Magee; - Hospital | | P < 0.001 | Pneumonia, N (%)
Exclusion criteria | | Maternal weight on admission, % >91 kg | G1: 17 (0.1)
- NR | | G1: 16.6 | G2: 9 (0.2)
Groups | | G2: 13.9 | G3: 2 (0.3)
G1: Spontaneous vaginal | | G3: 25.6 | G4: 4 (0.1)
G2: Operative vaginal | | G4: 25.7 | G5: 5 (0.7)
G3: Primary cesarean without trial of labor | | G5: 29.2 | G6: 4 (0.5)
G4: Primary cesarean with trial of labor | | G6: 26.8 | PP hemorrhage, N (%)
G5: Repeat cesarean with trial of labor | | P < 0.001 | G1: 1,105 (5.0)
G6: Repeat cesarean without trial of labor | | Gravidity, median (range) | G2: 231 (4.7)
N at enrollment | | G1: 39 (37–44) | G3: 18 (2.7)
G1: 22,270 | | G2: 39 (37–43) | G4: 131 (3.9)
G2: 4,908 | | G3: 39 (37–42) | G5: 20 (2.6)
G3: 657 | | G4: 40 (37–44) | G6: 28 (3.2)
G4: 3,366 | | G5: 39 (37–42) | Transfusion, N (%)
G5: 768 | | G6: 39 (37–43) | G1: 40 (0.2)
G6: 865 | | P < 0.001 | G2: 21 (0.4)
| | N of previous c/d | G3: 3 (0.3)
| | NR | G4: 36 (1.1)
| | Type of Labor | G5: 6 (0.8)
| | NR | G6: 4 (0.5)
| | Type of Anesthesia | Deep venous thrombosis, N (%)
| | NR | G1: 15 (0.1)
| | Gestational Age, median wks (range) | G2: 2 (0.04)
| | G1: 2 (1–18) | G3: 1 (0.2)
| | G2: 2 (1–18) | G4: 10 (0.3)
| | G3: 1 (1–8) | G5: 1 (0.1)
| | G4: 1 (1–11) | G6: 0
| | G5: 3 (2–10)
| | G6: 1 (1–11)
| | P < 0.001
| | Fetal weight
| | NR
| | Maternal Race, %
| | White, Black
| | G1: 81.2, 15.5
| | G2: 78.2, 17.7
| | G3: 87.5, 9.3
| | G4: 81.7, 14.9
| | G5: 84.1, 16.1
| | G6: 85.7, 12.1
| | P0< 0.001 (white only)
| | Marital Status
| | Married, %
| | G1: 61.3
| | G2: 58.7
| | G3: 59.4
| | G4: 66.2
| | G5: 71.7
| | G6: 76.5
| | Pregnancy Related Conditions
| | Preeclampsia, N (%)
| | G1: 1.9
| | G2: 2.7
| | G3: 3.5
| | G4: 5.9
| | G5: 1.3
| | G6: 1.2
| | P < 0.001
| | Episiotomy, %
| | G1: 52.1
| | G2: 67.6
| | G3: 0
| | G4: .2
| | G5: .1
| | G6: 0
| | P < 0.001
Author | Objective of the study | Maternal age, median yrs (range) | NR | 6 weeks (%): | Relevance
Farrell, Allen, and Baskett, 2001 | To estimate the incidence and relative risk of postpartum urinary incontinence in primaparas by urinary continency before pregnancy | Overall: 28 (15–48) | | G1: 8 | Moderate
Country, Setting | Definition of elective cesarean | Maternal BMI | | - G1a: 4; - G1b: NR; - G1c: 5 | Quality Rating
Canada, hospital-based | Does not include labored births | NR | | G2: 23 | Fair
Study design | | Gravidity | | G3a: 35
Prospective cohort | | NR | | G3b: NR
Inclusion criteria | | N of previous cesareans | | RR for G2 vs G1: 2.8 (1.5, 5.3)
- Nulliparity | | NR | | RR for G3a vs G1: 4.3 (2.2, 8.2)
Exclusion criteria | | Diabetes | | 6 months (%):
- Hx of urinary tract abnormalities, pelvic surgery; - Significant medical illness; - Medications that would alter urinary tract function | | NR | | G1: 10
Groups | | Gestational age | | - G1a: 5; - G1b: NR; - G1c: 3
G1: Cesarean delivery | | NR | | G2: 22
G1a: Before labor | | Type of labor | | G3a: 33
G1b: 1st stage | | NR | | G3b: NR
G1c: 2nd stage | | Type of anesthesia | | RR for G2 vs G1: 2.1 (1.1, 3.7)
G2: Spontaneous vaginal delivery | | NR | | RR for G3a vs G1: 3.1 (1.7, 5.9)
G3: Instrumental delivery | | Fetal weight, grams
G3a: Forceps | | NR
G3b: Vacuum | | Urinary incontinence before pregnancy, N (%)
N at enrollment | | G1a: 5 (6.3)
Total: 690 | | G1b: 13 (16.3)
Loss participants: 95 delivered at another hospital; 2 withdrawn (stillbirth = 1; neonatal death = 1) | | G1c: 4 (5.0)
N (%) | | G2: 46 (57.5)
G1: 147/593 | | G3a: 1 (1.3)
G1a: 32/593 | | G3b: 11 (13.8)
G1b: 70/593
G1c: 45/593
G2: 331/593
G3: 115/593
G3a: 100/395
G3b: 15/593
Follow-up
- At 6 weeks: 559 completers; - At 6 months: 484 completers
Author | Objective of the study | Maternal age median yrs (range) | NR | Flatal Incontinence at 6 wks PP, % | Relevance
Farrell, Allen, and Basket, 2001 | To estimate the incidence and relative risk (RR) of postpartum anal incontinence in primiparous women in a tertiary Canadian obstetrical unit | NR | | G1: 16 | Moderate
Setting | Definition of elective cesarean | Maternal BMI | | G2: 31 | Quality Ratings
Canada, Hospital | NR | NR | | G3: 17 | Fair
Study design | Category includes: | Gravidity | | G4: 34
Prospective Cohort | | NR | | Fecal Incontinence at 6 wks PP, %
Inclusion criteria | | N of previous cesareans | | G1: NR
- Nulliparity; - No tx of urinary or alimentary tract abnormalities; - No pelvic surgeries | | NR | | G2: NR
Exclusion criteria | | Diabetes | | G3: NR
- Medication with impact on urinary or alimentary tract function; - Significant medical illness | | NR | | G4: NR
Groups | | Gestational age | | Flatal Incontinence at 6 mos PP, %
G1: Spontaneous vaginal delivery | | NR | | G1: 17
G2: Elective c/d | | Type of labor | | G2: 0
G3: C/d in labor | | NR | | G3: 21
G4: Forceps delivery | | Type of anesthesia | | G4: 44
N (%) | | NR | | Fecal Incontinence at 6 mos PP, %
G1: 333 (56) | | Fetal weight, median gms | | G1: 4
G2 and G3: 147 (25) | | Overall: 3489 | | G2: 4
G4: 115 (19) | | Urinary incontinence before pregnancy, N (%) | | G3: 2
| | NR | | G4: 9
Author | Objective of the study | Maternal age, mean yrs ± SD | Perception of birth experience, mean score ± SD | NR | Relevance
Fawcett, Pollio, and Tully, 1992 | To examine women's birth experience by replicating Cranley et al., 1983 study | G1: 31.04 ± 4.5 | Day 1 to 2 PP | | Moderate
Setting | Definition of elective cesarean | G2: 31.56 ± 4.6 | G1: 3.40± 0.59 | | Quality rating
US, hospital-based | Planned by end of 2^nd^ trimester: 59% | G3: 26.69 ± 4.3 | G2: 3.45 ± 0.53 | | Poor
Study design | Planned within 1 to 9 weeks before delivery: 41% | P < 0.001 | G3: 3.65 ± 0.48
Prospective cohort | Probably includes labored, number | Maternal BMI | P < 0.001
Inclusion criteria | NR | NR | G1 vs G3: P < 0.017
- NR | Category includes | Primipara, % | Pain intensity, mean score ± SD
Exclusion criteria | G1:; - Fetopelvic disproportion (37%); - Fetal distress (26%); - Breech presentation (18%); - Failed induction (4%); - Combination (15%) | G1: 88 | Day 1 to 2 PP
- NR | G2:; - Repeat c/d (60%); - Breech (18%); - Combination (22%) | G2: 12 | G1: 2.64 ± 0.86
Groups | | G3: 90 | G2: 2.45 ± 0.73
G1: Unplanned c/d | | G1 vs G3: P < 0.001 | G3: 2.64 ± 0.96
G2: Planned c/d | | N of previous cesareans | P: NS
G3: Vaginal delivery | | NR | Physical distress, mean score ± SD
N | | Diabetes | G1: 1.39 ± 0.94
G1: 106/473 (22.4%) | | NR | G2: 1.17 ± 0.87
G2: 113/473 (23.9%) | | Gestational age | G3: 1.03 ± 0.95
G3: 254/473 (53.7%) | | NR | P = 0.004
| | Type of labor | G1 vs G3: P < 0.17
| | NR
| | Type of anesthesia
| | Not reported by group
| | Fetal weight
| | NR
| | Father Not Present at Births, N
| | G1: 1
| | G2: 6
| | G3: 1
| | Moms who held baby immediately after delivery, %
| | G1: 18
| | G2: 18
| | G3: 73
| | P < 0.001
| | G3 vs G2 and G1: P 0.05
| | Hospital stay, mean days (range)
| | G1: 4.8 (3–10)
| | G2: 4.9 (3–12)
| | G3: 2.5 (1–14)
| | P < 0.001
| | G3 vs G2 and G1: P 0.05
Author | Objective of the study | Maternal age, mean yrs ± SD | NR | Stress incontinence at 1 yr, N (%) | Relevance
Groutz et al., 2003 | To compare prevalence of stress urinary incontinence by mode of delivery | G1: 28 ± 4 | | G1: 15/145 (10.3) | Moderate
Country, Setting | Definition of elective cesarean | G2: 32.5 ± 5.3 | | G2: 12/100 (12) | Quality rating
Israel, hospital-based | No trial of labor | G3: 31.7 ± 5.2 | | G3: 4/118 (3.4) | Fair
Study design | Category includes:; - Breech (70%); - Other indications not specified | Maternal height, mean cm ± SD | | G1 vs G2
Prospective cohort | | G1: 164 ± 6.6 | | P = 0.7
Inclusion criteria | | G2: 162 ± 5.6 | | G1 vs G3
- Primiparous; - Delivery at Lis Maternity Hospital | | G3: 164 ± 6.7 | | P = 0.02
Exclusion criteria | | Maternal weight, mean kg ± SD
- Nonsingleton deliveries; - Instrumental vaginal delivery; - Those with SUI before pregnancy | | G1: 60 ± 9.0
Groups | | G2: 62.5 ± 1.6
G1: Spontaneous vaginal delivery | | G3: 63 ± 13.0
G2: Obstructed labor cesarean delivery | | Parity, %
G3: Elective cesarean delivery | | Primiparous: 100%
N at enrollment | | N of previous cesareans
G1: 145 | | NR
G2: 100 | | Diabetes
G3: 118 | | NR
Follow-up | | Gestational age, wks ± SD
1 year | | G1: 39.7 ± 1.2
G1: 145 | | G2: 40.2 ± 1.3
G2: 100 | | G3: 38.8 ± 1.5
G3: 118 | | Type of labor
| | NR
| | Type of anesthesia Epidural
| | G1: 134/145
| | G2: NR
| | G3: NR
| | Fetal weight, mean ± SD
| | G1: 325 ± 400
| | G2: 3450 ± 420
| | G3: 3260 ± 617
| | P < 0.05
| | SUI during Pregnancy, N (%)
| | G1: 45 (31)
| | G2: 25 (25)
| | G3: 33 (28)
Author | Objective of the study | Maternal Age, N (%) | Maternal Mortality, N (%) | Early PP depression | Relevance
Hannah, Hannah, Hewson, et al., 2000 | To compare a policy of planned c/d with policy of planned vaginal birth for selected breech presentation | ≥ 30 | G1: 0 | G1: 3 (.3) | T
Setting | Definition of elective cesarean | G1: 339 (32.6) | G2: 1 (0.1) | G2: 0 | Quality Rating
Australia, Canada, Chile, Denmark, Finland, Germany, Israel, Netherlands, New Zealand, Poland, Portugal, Romania, Switzerland, U.K., U.S., Yugoslavia; hospital/labor and delivery unit/maternity unit/outpatient clinic/NICU | Planned cesarean scheduled for 38 or more wks gestation | G2: 331 (31.8) | Wound Infection dehiscence or breakdown, N (%) | | Fair
Study design | Includes actual vaginal deliveries | < 30 | G1: 16 (1.5)
RCT | Category includes:; - breech | G1: 702 (67.4) | G2: 10 (1.0)
Inclusion criteria | | G2: 711 (68.2) | P = .32
- Singleton, frank or complete breech; - ≥ 37 wks | | Maternal BMI | Infection
Exclusion criteria | | NR | G1: 15 (1.4)
- Evidence of fetopelvic disproportion; - Clinically large infant; - EFW ≥ 4000 g; - Fetal hyperextension of head; - Fetal anomaly; - Contraindication to either labor or vaginal delivery | | Parity, N (%) | G2: 9 (0.9)
Groups | | 0 | Dehiscence or breakdown
G1: Planned c/d | | G1: 547 (52.6) | G1: 6 (0.6)
G2: Planned vaginal delivery | | G2: 545 (52.3) | G2: 2 (0.2)
N at randomization | | 1–4 | Maternal recovery
G1:; - 1,043/1,043; - Lost to F/U: 2; - Analyzed maternal outcomes: 1,041/1,043 | | G1: 434 (41.7) | G1: 4.0 (1.7–7.4)
G2:; - 1,045/1,045; - Lost to F/U: 3; - Analyzed maternal outcomes: 1,042/1,045 | | G2: 434 (41.7) | G2: 2.8 (0.8–6.9)
| | > 4 | P < 0.0001
| | G1: 60 (5.8) | Postpartum bleeding, N (%)
| | G2: 63 (6.1) | G1: 10 (1.0)
| | Time from randomization to delivery ≥ 7days, N (%) | G2: 13 (1.3)
| | G1: 156 (15.0) | P = 0.68
| | G2: 301 (28.9) | Hemorrhage, N (%)
| | P < 0.0001 | > 1000 ml
| | Gestational Age/pregnancy dating ≥ 41 wks, N (%) | G1: 4 (.4)
| | G1: 67 (6.4) | G2: 8 (.8)
| | G2: 65 (6.2) | Hemorrhage
| | Gestational Age, median wks (5th to 95th percentile), N (%) | > 1500 ml
| | G1: 39.3 (37.5; 41.2) | G1: 2 (.2)
| | G2: 39.6 (37.5; 41.8) | G2: 4 (.4)
| | P < 0.0001 | P = 0.68
| | Presentation, N (%) | Hemorrhage
| | Frank | Requiring transfusion
| | G1: 655 (62.9) | G1: 4 (.4)
| | G2: 637 (61.1) | G2: 8 (.8)
| | Complete | Hemorrhage
| | G1: 340 (32.7) | Requiring D&C
| | G2: 362 (34.7) | G1: 3 (.3)
| | Uncertain | G2: 4 (.4)
| | G1: 46 (4.4) | Hemorrhage
| | G2: 43 (4.1) | Other
| | In labor | G1: 2 (.2)
| | G1: 434 (41.7) | G2: 1 (.1)
| | G2: 456 (43.8) | Maternal Systemic Infection, N (%)
| | Rupture of membranes | G1: 16 (1.5)
| | (N, %) | G2: 13 (1.0)
| | G1: 253 (24.3) | P = 0.71
| | G2: 233 (22.4) | PP fever, N (%)
| | FHR abnormalities, N (%) | ≥ 38.0
| | G1: 13 (1.3) | G1: 16 (1.5)
| | G2: 156 (15.2) | G2: 13 (1.3)
| | P = < 0.0001 | ≥ 38.5
| | Fetal weight, estimated gms (%) | G1: 13 (1.3)
| | ≥ 3000 gms | G2: 10 (1.0)
| | G1: 689 (66.2) | Pneumonia, N (%)
| | G2: 680 (65.3) | G1: 1 (.1)
| | < 3000 g | G2: 0
| | G1: 352 (33.8) | Infection, N (%)
| | G2: 362 (34.7) | G1: 1 (.1)
| | Method of estimated fetal weight, N (%) | G2: 1 (.1)
| | Clinical only | Deep vein thromophlebitis or pulmonary embolism
| | G1: 418 (40.2) | G1: 0
| | G2: 427 (41.0) | G2: 0
| | Ultrasonograph
| | G1: 623 (59.9)
| | G2: 615 (59.0)
| | General anesthesia (N, %)
| | G1: 294 (28.2)
| | G2: 132 (12.7)
| | P < 0.0001
| | Epidural/spinal, N (%)
| | G1: 682 (65.5)
| | G2: 482 (46.3)
| | P < 0.0001
| | C/d before labor, N (%)
| | G1: 470 (45.2)
| | G2: 75 (7.2)
| | C/d after labor, N (%)
| | G1: 471 (45.2)
| | G2: 376 (36.1)
| | Vag delivery, N (%)
| | G1: 100 (9.6)
| | G2: 591 (56.7)
| | P < 0.0001
| | Cord prolapse, N (%)
| | Before labor
| | G1: 0
| | G2: 2
| | During labor
| | G1: 0
| | G2: 12
| | P < 0.0001
| | Chorioamnionitis, N (%)
| | G1: 3 (0.3)
| | G2: 11 (1.1)
| | Time in hosp before deliv ≥ 48 h, N (%)
| | G1: 74 (7.1)
| | G2: 91 (8.8)
| | P = 0.19
| | Maternal BMI
| | NR
Author | Objective of the study | Maternal age, N (%) | Breastfed w/in a few hours following birth, N (%) | Experienced urinary incontinence, N (%) | Relevance
Hannah, Hannah, Hodnett, et al., 2002 | To compare maternal outcomes of planned c/d delivery and planned vaginal birth at 3 mos PP | ≥ 30 y | G1: 571/779 (73.3) | G1: 36/798 (4.5) | T
Setting | Definition of elective cesarean | G1: 286 (35.8) | G2: 602/776 (77.6) | G2: 58/797 (7.3) | Quality Rating
26 different countries, 1,596 of 1,940 women from 110 centers worldwide with singleton fetus, in breech presentation at term | Planned cesarean scheduled for 38 or more wks gestation | G2: 285 (35.7) | RR: 0.94 (0.89–1.00) | RR: 0.62 (.41–.93) | Poor
Study design | Includes actual vaginal deliveries | Married or stable relationship, N (%) | P = 0.05 | P = 0.02
RCT | Category includes:; - breech | G1: 745 (93.4) | Breastfed at time of completion of questionnaire, N (%) | No problem at all
Inclusion criteria | | G2: 747 (93.6) | G1: 533/781 (68.3) | G1: 4/24 (16.7)
- Singleton; - Frank or complete breech; - ≥ 37 weeks | | Nulliparity, N (%) | G2: 539/776 (69.5) | G2: 17/46 (37.0)
Exclusion criteria | | G1: 399 (50.0) | RR: 0.98 (0.92–1.05) | P = 0.09
- NR | | G2: 403 (50.5) | P = 0.62 | A little problem
Groups | | Previous c/d | Postoperative or postpartum pain (3 months PP), N (%) | G1: 15/24 (62.5)
G1: Planned c/d | | G1: 24 (3.0) | In back | G2: 23/46 (50.0)
G2: Planned vag | | G2: 20 (2.5) | G1: 90/796 (11.3) | P = 0.09
N at randomization | | In labor at randomization, N (%) | G2: 97/797 (12.2) | A big problem
G1: 1,043 | | G1: 322 (40.4) | RR: 0.93 (.71–1.22) | G1: 5/24 (20.8)
G2: 1,045 | | G2: 341 (42.7) | P = 0.64 | G2: 6/46 (13.0)
Follow-up | | Planning to breastfeed, N (%) | In head | P = 0.09
3 months PP | | Yes | G1: 38/796 (4.8) | Experienced fecal incontinence, N (%)
| | G1: 707 (88.6) | G2: 34/797 (4.3) | G1: 5/619 (0.8)
| | G2: 707 (88.6) | RR: 1.12 (0.71–1.76) | G2: 9/607 (1.5)
| | No | P = 0.63 | RR: 0.54 (0.18–1.62)
| | G1: 42 (5.3) | On outside of abdomen | P = 0.29
| | G2: 43 (5.4) | G1: 79/796 (9.9) | No problem at all
| | Unknown | G2: 45/797 (5.7) | G1: 2/4 (50.0)
| | G1: 49 (6.1) | RR: 1.76 (1.24–2.50) | G2: 2/9 (22.2)
| | G2: 48 (6.0) | P = 0.002 | P = 0.53
| | Ruptures of membranes, N (%) | Deep inside abdomen | A little problem
| | G1: 183 (22.9) | G1: 70/796 (8.8) | G1: 2/4 (50.0)
| | G2: 163 (20.4) | G2: 37/797 (4.6) | G2: 7/9 (77.8)
| | Time from delivery to questionnaire completion, median months (5th to 95th percentile) | RR: 1.89 (1.29–2.79) | P = 0.53
| | G1: 3.1 (2.5–7.5) | P < 0.001 | Experienced incontinence of flatus, N (%)
| | G2: 3.1 (2.5–6.7) | In bottom of genital area | G1: 66/616 (10.7)
| | Questionnaire method, N (%) | G1: 14/796 (1.8) | G2: 59/606 (9.7)
| | Mail | G2: 44/797 (5.5) | RR: 1.10 (.79–1.54)
| | G1: 219 (27.4) | RR: 0.32 (0.18–.58) | P = 0.64
| | G2: 216 (27.1) | P < 0.001 | No problem at all
| | Telephone/In person | In other location | G1: 40/61 (65.6)
| | G1: 563 (70.6) | G1: 13/796 (1.6) | G2: 23/58 (39.7)
| | G2: 564 (70.7) | G2: 16/797 (2.0) | P = 0.006
| | Unknown | RR: 0.81 (0.39–1.68) | A little problem
| | G1: 16 (2.0) | P = 0.71) | G1: 20/61 (32.8)
| | G2: 18 (2.3) | Any pain | G2: 33/58 (56.9)
| | Received help answering questionnaire, N (%) | G1: 217/796 (27.3) | P = 0.006
| | Yes | G2: 199/797 (25.0) | A big problem
| | G1: 415 (52.0) | RR: 1.09 (0.93–1.29) | G1: 1/61 (1.8)
| | G2: 421 (52.8) | P = 0.31 | G2: 2/58 (3.5)
| | No | Amount of pain, N (%) | P = 0.006
| | G1: 349 (43.7) | None | No sex since birth, N (%)
| | G2: 329 (41.2) | G1: 579/796 (72.7) | G1: 129/795 (16.2)
| | Unknown | G2: 598/795 (75.2) | G2: 115/796 (14.5)
| | G1: 34 (4.3) | Almost none | RR: 1.12 (.89–1.42)
| | G2: 48 (6.0) | G1: 22/796 (2.8) | P = 0.33
| | Low perinatal mortality rate, N (%) | G2: 23/795 (2.9) | Pain during sex on most recent occasion, N (%)
| | G1: 396 (49.6) | Mild or small amount | G1: 111/655 (17.0)
| | G2: 394 (49.4) | G1: 165/796 (20.7) | G2: 126/674 (18.7)
| | High perinatal mortality rate, N (%) | G2: 142/795 (17.9) | RR: 0.91 (.72–1.14)
| | G1: 402 (50.4) | Quite a lot | P = 0.43
| | G2: 404 (50.6) | G1: 29/796 (3.6) | Experienced PP depression, N (%)
| | Diabetes | G2: 31/795 (3.9) | G1: 80/793 (10.1)
| | NR | Severe or excruciating/terrible | G2: 46/454 (10.1)
| | Gestational age | G1: 1/796 (0.1) | RR: 0.93 (0.70–1.24)
| | NR | G2: 1/795 (0.1) | P = 0.68
| | Type of labor | Took pills or medicine for pain in last 24 h, N (%)
| | NR | G1: (46/795)
| | Type of anesthesia | G2: (46/793)
| | NR | 1.0 (0.67–1.48)
| | Fetal weight, grams | RR: P>.99
| | NR | Experienced PP depression, N (%)
| | | G1: 80/793 (10.1)
| | | G2: 46/454 (10.1)
| | | RR: 0.93 (0.70–1.24)
| | | P = 0.68
| | | Regarding childbirth experience, N (%)
| | | Liked that it was natural
| | | G1: 62 (7.8)
| | | G2: 357 (44.7)
| | | RR: 0.17 (.14–.22)
| | | P < 0.001
| | | Liked that childbirth was not very painful
| | | G1: 387 (48.5)
| | | G2: 329 (41.2)
| | | RR: 1.18 (1.05–1.31)
| | | P = 0.004
| | | Liked being able to schedule the delivery
| | | G1: 261 (32.7)
| | | G2: 131 (16.4)
| | | RR: 1.99 (1.66–2.40)
| | | P < 0.001
| | | Liked the method of delivery
| | | G1: 469 (58.8)
| | | G2: 478 (59.9)
| | | RR: 0.98 (.90–1.06)
| | | P = 0.68
| | | Liked actively participating in birth
| | | G1: 141 (17.7)
| | | G2: 381 (47.7)
| | | RR: 0.37 (.31–.44)
| | | P < 0.001
| | | Felt reassured about own health
| | | G1: 539 (67.5)
| | | G2: 530 (66.4)
| | | RR: 1.02 (.95–1.09)
| | | P = 0.67
| | | Felt reassured about infant's health
| | | G1: 618 (77.4)
| | | G2: 547 (68.6)
| | | RR: 1.13 (1.06–1.20)
| | | P < 0.001
| | | Liked that recovering from childbirth was not difficult
| | | G1: 410 (51.4)
| | | G2: 488 (61.2)
| | | RR: 0.84 (.77–.92)
| | | P < 0.001
| | | Liked nothing about childbirth experience
| | | G1: 37 (4.6)
| | | G2: 37 (4.6)
| | | RR: 1.00 (.64–1.56)
| | | P>.99
| | | Disliked that childbirth was very painful
| | | G1: 62 (7.8)
| | | G2: 109 (13.7)
| | | RR: 0.57 (.42–.76)
| | | P < 0.001
| | | Disliked that childbirth was not natural
| | | G1: 173 (21.7)
| | | G2: 117 (14.7)
| | | RR: 1.48 (1.19–1.83)
| | | P = < 0.001
| | | Disliked the method of delivery
| | | G1: 113 (14.2)
| | | G2: 106 (13.3)
| | | RR: 1.07 (.83–1.36)
| | | P = 0.66
| | | Disliked not being able to actively participate in birth
| | | G1: 172 (21.6)
| | | G2: 115 (14.4)
| | | RR: 1.50 (1.21–1.85)
| | | P < 0.001
| | | Disliked planning for one method of delivery but having another
| | | G1: 80 (10.0)
| | | G2: 125 (15.7)
| | | RR: 0.64 (.49–.83)
| | | P < 0.001
| | | Felt worried about own health
| | | G1: 112 (14.0)
| | | G2: 95 (11.9)
| | | RR: 1.18 (.91–1.52)
| | | P = .23
| | | Felt worried about infant's health
| | | G1: 136 (17.0)
| | | G2: 226 (28.3)
| | | RR: 1.14 (.93–1.41)
| | | P = .24
| | | Disliked that recovering from childbirth was difficult
| | | G1: 152 (19.1)
| | | G2: 133 (16.7)
| | | RR: 1.14 (.93–1.41)
| | | P = .24
| | | Disliked nothing about childbirth experience
| | | G1: 334 (41.9%)
| | | G2: 325 (40.7%)
| | | RR: 1.03 (.91–1.16)
| | | P = 0.68
Author | Objective of the study | Maternal age, N ≥ 30 yrs (%) | Breastfed at time of completion of questionnaire, N (%) | Experience of being a mother | Relevance
Hannah, Whyte, Hannah, et al., 2004 | To compare maternal outcomes at two years postpartum after planned vaginal birth for the singleton fetus in breech presentation at term. | G1: 184 (40.3) | G1: 35 (7.7) | G1: 428 | T
Setting | Definition of elective cesarean | G2: 181 (39.3) | G2: 24 (5.3) | G2: 446 | Quality Rating
26 different countries, 917 of 1,159 women from 85 centers involved in a 2-yr postpartum follow-up study | Planned cesarean scheduled for 38 or more wks gestation | Maternal BMI | P = 0.14 | P = 0.41 | Poor
Study design | Includes actual vaginal deliveries | NR | Duration of breast feeding, median months (5th,95th percentile) | Very easy, N (%)
RCT | Category includes:; - breech | Nulliparity, N (%) | G1: 8.0 (1.0, 24.1) | G1: 65 (15.2)
Inclusion criteria | | G1: 198 (43.3) | G2: 8.0 (1.0, 23.0) | G2: 74 (16.6)
- Singleton; - Frank or complete breech; - ≥ 37 weeks | | G2: 221 (48.0) | P = 0.57 | Easy, N (%)
Exclusion criteria | | N of previous cesareans | Ease of caring for child | G1: 306 (71.5)
- NR | | NR | G1: 430 | G2: 310 (69.5)
Groups | | Previous c/d, N (%) | G2: 443 | Difficult, N (%)
G1: Planned c/d | | G1: 13.8 (2.8) | P = 0.78 | G1: 51 (11.9)
G2: Planned vag | | G2: 8 (1.7) | Very easy, N (%) | G2: 60 (13.5)
N at randomization | | Diabetes | G1: 100 (23.3) | Very difficult, N (%)
G1: 1,043 | | NR | G2: 95 (21.4) | G1: 6 (1.4)
G2: 1,045 | | Gestational age | Easy, N (%) | G2: 2 (0.4)
Follow-up | | NR | G1: 257 (59.8) | Relationship with husband/partner
2 yrs PP | | Type of labor | G2: 270 (60.9) | G1: 430
| | NR | A little difficult, N (%) | G2: 426
| | Type of anesthesia | G1: 68 (15.8) | P = 0.62
| | NR | G2: 75 (16.9) | Very happy, N (%)
| | Fetal weight | Very difficult, N (%) | G1: 247 (57.4)
| | NR | G1: 5 (1.2) | G2: 249 (58.5)
| | Married or stable relationship, N (%) | G2: 3 (0.7) | Somewhat happy, N (%)
| | G1: 439 (96.1) | | G1: 152 (35.3)
| | G2: 441 (95.9) | | G2: 147 (34.5)
| | In labor at randomization, N (%) | | Somewhat unhappy, N (%)
| | G1: 170 (37.2) | | G1: 21 (4.9)
| | G2: 196 (42.6) | | G2: 25 (5.9)
| | Planning to breastfeed (N, %) | | Very unhappy, N (%)
| | Yes | | G1: 10 (2.3)
| | G1: 398 (87.1) | | G2: 5 (1.2)
| | G2: 402 (87.4) | | Relationship with husband/partner now compared to before child
| | No | | G1: 428
| | G1: 25 (5.5) | | G2: 424
| | G2: 31 (6.7) | | P = 0.39
| | Unknown | | Better, N (%)
| | G1: 34 (7.4) | | G1: 92 (21.5)
| | G2: 27 (5.9) | | G2: 79 (18.6)
| | Ruptures of membranes, N (%) | | About the same, N (%)
| | G1: 89 (19.5) | | G1: 310 (72.4)
| | G2: 95 (20.7) | | G2: 319 (75.2)
| | Time from delivery to questionnaire completion, median months (5^th^, 95^th^ percentile) | | Worse
| | G1: 24.3 (23.0, 30.8) | | G1: 26 (6.1)
| | G2: 24.2 (23.0, 29.9) | | G2: 26 (6.1)
| | Method of completing questionnaire, N (%) | | No sex, N (%)
| | Mail | | G1: 32 (7.0)
| | G1: 190 (41.6) | | G2: 41 (8.9)
| | G2: 189 (41.1) | | P = 0.33
| | Telephone/personal interview | | Pain during sex
| | G1: 263 (57.5) | | G1: 418
| | G2: 267 (58.0) | | G2: 412
| | Unknown | | P = 0.84
| | G1: 4 (0.9) | | No pain, N (%)
| | G2: 4 (0.9) | | G1: 376 (90.0)
| | Received help answering questionnaire, N (%) | | G2: 369 (89.6)
| | Yes | | Almost no pain, N (%)
| | G1: 240 (52.5) | | G1: 5 (1.2)
| | G2: 263 (57.2) | | G2: 8 (1.9)
| | No | | Mild or small amount of pain, N (%)
| | G1: 214 (46.8) | | G1: 28 (6.7)
| | G2: 194 (42.2) | | G2: 29 (7.0)
| | Unknown | | Quite a lot of pain, N (%)
| | G1: 3 (0.7) | | G1: 8 (1.9)
| | G2: 3 (0.7) | | G2: 6 (1.5)
| | Low perinatal mortality rate, N (%) | | Severe or excruciating/terrible pain, N (%)
| | G1: 270 (59.1) | | G1: 1 (0.2)
| | G2: 262 (57.0) | | G2: 0 (0)
| | High perinatal mortality rate, N (%) | | Happiness with sexual relations
| | G1: 187 (40.9) | | G1: 353
| | G2: 198 (43.0) | | G2: 349
| | | | P = 0.72
| | | | Very happy, N (%)
| | | | G1: 181 (51.3)
| | | | G2: 172 (49.3)
| | | | Somewhat happy, N (%)
| | | | G1: 149 (42.2)
| | | | G2: 151 (43.3)
| | | | Somewhat unhappy, N (%)
| | | | G1: 18 (5.1)
| | | | G2: 23 (6.6)
| | | | Very unhappy, N (%)
| | | | G1: 5 (1.4)
| | | | G2: 3 (0.9)
| | | | Tried to become pregnant since the birth of the child, N (%)
| | | | G1: 88 (19.3)
| | | | G2: 105 (22.9)
| | | | P = 0.20
| | | | Number of pregnancies after the birth in the Term Breech Trial, N (%)
| | | | 1 or more
| | | | G1: 95 (21.0)
| | | | G2: 102 (22.3)
| | | | P = 0.69
| | | | 0
| | | | G1: 358 (79.0)
| | | | G2: 356 (77.7)
| | | | P = 0.69
| | | | Currently pregnant or one or more infants born after the birth in the Term Breech Trial, N (%)
| | | | G1: 78 (17.2)
| | | | G2: 84 (18.3)
| | | | P = 0.67
| | | | Cesarean for one or more infants born after the birth in the Term Breech Trial, N (%)
| | | | G1: 16 (3.6)
| | | | G2: 13 (2.9)
| | | | P = 0.58
| | | | Urinary incontinence (N, %)
| | | | G1: 81(17.8)
| | | | G2: 100 (21.8)
| | | | 0.81 (0.63–1.06)
| | | | P = 0.14
| | | | Problem caused by urinary incontinence
| | | | G1:81
| | | | G2: 100
| | | | P = 0.46
| | | | No problem at all, N (%)
| | | | G1: 31 (38.3)
| | | | G2: 37 (37.0)
| | | | A little problem, N (%)
| | | | G1: 47 (58.0)
| | | | G2: 54 (54.0)
| | | | A big problem, N (%)
| | | | G1: 3 (3.7)
| | | | G2: 9 (9.0)
| | | | Fecal incontinence, N (%)
| | | | G1: 11 (2.4)
| | | | G2: 10 (2.2)
| | | | P = 0.83
| | | | 1.10 (0.47–2.58)
| | | | Problem caused by fecal incontinence
| | | | G1: 11
| | | | G2: 9
| | | | P = 0.41
| | | | No problem at all, N (%)
| | | | G1: 3 (27.3)
| | | | G2: 2 (22.2)
| | | | A little problem, N (%)
| | | | G1: 7 (63.6)
| | | | G2: 4 (44.4)
| | | | A big problem, N (%)
| | | | G1: 1 (9.1)
| | | | G2: 3 (33.3)
| | | | Incontinence of flatus, N (%)
| | | | G1: 60 (13.1)
| | | | G2: 53 (11.5)
| | | | 1.14 (0.80–1.61)
| | | | P = 0.48
| | | | Problem caused by incontinence of flatus
| | | | G1: 60
| | | | G2: 53
| | | | P = 0.50
| | | | No problem at all, N (%)
| | | | G1: 33 (55.0)
| | | | G2: 34 (64.2)
| | | | A little problem, N (%)
| | | | G1: 22 (36.7)
| | | | G2: 17 (32.1)
| | | | A big problem, N (%)
| | | | G1: 5 (8.3)
| | | | G2: 2 (3.8)
| | | | Post partum depression, (%)
| | | | G1: 47 (10.5)
| | | | G2: 53 (11.6)
| | | | 0.90 (0.62–1.30)
| | | | P = 0.60
| | | | Painful menstrual periods, N (%)
| | | | G1: 95 (24.7)
| | | | G2: 106 (28.0)
| | | | 0.88 (0.70–1.12)
| | | | P = 0.32
| | | | Problem caused by painful menstrual period
| | | | G1: 89
| | | | G2: 104
| | | | P = 0.46
| | | | No problem at all, N (%)
| | | | G1: 13 (14.6)
| | | | G2: 26 (25.0)
| | | | A little problem, N (%)
| | | | G1: 67 (75.3)
| | | | G2: 63 (60.6)
| | | | A big problem, N (%)
| | | | G1: 9 (10.1)
| | | | G2: 15 (14.4)
| | | | Irregular menstrual periods, N (%)
| | | | G1: 39 (11.0)
| | | | G2: 53 (15.0)
| | | | 0.73 (0.50–1.08)
| | | | P = 0.12
| | | | Problem caused by irregular menstrual period
| | | | G1: 37
| | | | G2: 52
| | | | P = 0.83
| | | | No problem at all, N (%)
| | | | G1: 15 (40.5)
| | | | G2: 21 (40.4)
| | | | A little problem, N (%)
| | | | G1: 15 (40.5)
| | | | G2: 23 (44.2)
| | | | A big problem, N (%)
| | | | G1: 7 (18.9)
| | | | G2: 8 (15.4)
| | | | Heavy menstrual period, N (%)
| | | | G1: 63 (18.4)
| | | | G2: 58 (16.8)
| | | | 1.10 (0.79–1.51)
| | | | P = 0.62
| | | | Problem caused by heavy menstrual period
| | | | G1: 62
| | | | G2: 56
| | | | P = 0.35
| | | | No problem at all, N (%)
| | | | G1: 15 (24.2)
| | | | G2: 13 (23.2)
| | | | A little problem, N (%)
| | | | G1: 38 (61.3)
| | | | G2: 29 (51.8)
| | | | A big problem, N (%)
| | | | G1: 9 (14.5)
| | | | G2: 14 (25.0)
| | | | Constipation, N (%)
| | | | G1: 124 (27.2)
| | | | G2: 93 (20.2)
| | | | 1.35 (1.06–1.70)
| | | | P = 0.02
| | | | Problem caused by constipation
| | | | G1: 122
| | | | G2: 93
| | | | P = 0.32
| | | | No problem at all, N (%)
| | | | G1: 25 (20.5)
| | | | G2: 24 (25.8)
| | | | A little problem, N (%)
| | | | G1: 79 (64.8)
| | | | G2: 58 (62.4)
| | | | A big problem, N (%)
| | | | G1: 18 (14.8)
| | | | G2: 11 (11.8)
| | | | Sexual problems, N (%)
| | | | G1: 36 (7.9)
| | | | G2: 38 (8.3)
| | | | 0.96 (0.62–1.49)
| | | | P = 0.90
| | | | Problem caused by sexual problems
| | | | G1: 36
| | | | G2: 38
| | | | P = 0.73
| | | | No problem at all, N (%)
| | | | G1: 2 (5.6)
| | | | G2: 4 (10.5)
| | | | A little problem, N (%)
| | | | G1: 20 (55.6)
| | | | G2: 22 (57.9)
| | | | A big problem, N (%)
| | | | G1: 14 (38.9)
| | | | G2: 12 (31.6)
Author | Objective of the study | Maternal age | Pyrexia, N (%) | NR | Relevance
Hillan, 1995 | To determine the post operative morbidity associated with caesarean delivery, including comparisons for elective and emergency caesarean delivery, subgroups within emergency caesarean delivery and first vs second stage of labor | NR | G1:106/220 (48.2) | | Moderate
Setting | Definition of elective cesarean | Maternal BMI | G2: 251/399 (62.9) | | Quality Rating
UK, hospital-based | Does not include labored births | NR | - G2a: 24/42 (57.1); - G2b: 58/109 (53.2); - G2c: 82/129 (63.6); - G2d: 87/119 (73.1) | | Poor
Study design | | Gravidity | P < 0.001 for G1 vs G2
Retrospective cohort | | NR | P < 0.025 for G2 subgroups
Inclusion criteria | | N of previous cesareans | Blood Transfusion, N (%)
- C/d during study period | | NR | G1: 3/220 (1.4)
Exclusion criteria | | Diabetes | G2: 18/399 (4.5)
- NR | | NR | - G2a: 7/42 (16.7); - G2b: 2/109 (1.8); - G2c: 5/129 (3.9); - G2d: 4/119 (3.4)
Groups | | Gestational age | P < 0.05 for G1 vs G2
G1: Elective c/d | | NR | P < 0.001 for G2 subgroups
G2: Emergent c/d | | Type of labor | Antibiotic Therapy, N (%)
- G2a: Emergency, no labor; - G2b: In labor, no data available; - G2c: Labor < 12 hrs; - G2d: Labor ≥ 12 hrs | | NR | G1:35/229 (15.9)
N | | Type of anesthesia | G2: 130/399 (32.6)
G2: 399 | | NR | - G2a: 15/42 (36.6); - G2b: 31/109 (28.4); - G2c: 44/129 (34.1); - G2d: 40/119 (33.6)
- G2a: 42; - G2b: 109; - G2c: 129; - G2d: 119 | | Fetal weight, grams | P < 0.001 G1 vs G2
| | | P NS for G2 subgroups
| | NR | Urinary tract infection, N (%)
| | | G1: 24/220 (10.9)
| | | G2: 41/399 (10.3)
| | | - G2a: 4/42 (9.5); - G2b: 9/109 (8.3); - G2c: 17/129 (13.2); - G2d: 11/119 (9.3)
| | | P NS for G1 vs G2
| | | P NS for G2 subgroups
| | | Wound infection, N (%)
| | | G1: 9/220 (4.1)
| | | G2: 33/399 (8.3)
| | | - G2a: 7/42 (16.7); - G2b: 5/109 (4.6); - G2c: 10/129 (7.8); - G2d: 11/119 (9.3)
| | | P < 0.05 for G1 vs G2
| | | P NS for G2 subgroups
| | | Intrauterine infection, N (%)
| | | G1: 3/220 (1.4)
| | | G2: 24/399 (6.0)
| | | - G2a: 3/42 (7.2); - G2b: 9/109 (8.3); - G2c: 7/129 (5.4); - G2d: 5/119 (4.2)
| | | P < 0.01 for G1 vs G2
| | | P NS for G2 subgroups
| | | Chest infection N (%)
| | | G1: 2/220 (0.9)
| | | G2: 21/399 (5.3)
| | | - G2a: 2/42 (4.8); - G2b: 11/109 (10.1); - G2c: 7/129 (5.5); - G2d: 1/119 (0.8)
| | | P < 0.05 for G1 vs G2
| | | P < 0.025 for G2 subgroups
Author | Objective of the study | Mean maternal age, mean yrs ± SD | Endometritis, N (%) | NR | Relevance
Irion et al 1998 | To compare maternal and neonatal outcomes in elective cesarean vs attempted vaginal delivery for breech presentation at term | G1: 29.0 ± 4.9 | G1: 7 (1.8) | | Low
Setting | Definition of elective cesarean | G2: 30.1 ± 5.2 | G2: 13 (4.1) | | Quality Rating
Switzerland, hospital-based | Probably ncludes labored births, number NR. | P = 0.004 | RR = 0.45 (0.18–1.11) | | Not rated
Study design | Category not defined | Maternal BMI, mean (IQ range) | P = 0.07
Retrospective cohort | | G1: 25.8 (23.9, 28.2) | UTI, N (%)
Inclusion criteria | | G2: 27.5 (24.9, 30.5) | G1: 20 (5.2)
For attempted vaginal delivery | | P < 0.001 | G2: 40 (12.5)
- EFW (clinically by U/S) ≤ 3600 gms; - BPD (≤ 96 MM); - No hyperextension by U/S; - Normal pelvis by digital exam | | Mean maternal height, mean cm ± SD | RR = 0.42 (0.25–0.70)
Exclusion criteria | | G1: 163.8 ± 6.5 | P < 0.001
- NR | | G2: 161.1 ± 7.1 | Pulmonary infection, N (%)
Groups | | P < 0.001 | G1: 3 (0.8)
G1: Attempted vaginal delivery | | Parity, N (%) | G2: 1 (0.3)
G2: Elective c/d | | 0 | RR = 2.49 (0.26–23.86)
N | | G1: 273 (70.9) | P = 0.63
G1: 385 | | G2: 209 (65.3) | Surgical complications, N (%)
G2: 320 | | 1 | G1: 3 (0.8)
| | G1: 86 (22.3) | G2: 1 (0.3)
| | G2: 81 (25.3) | RR = 2.49 (0.26–23.86)
| | ≥ 2 | P = 0.63
| | G1: 26 (6.8) | Hysterectomy for hemorrhage, N (%)
| | G2: 30 (9.4) | G1: 0
| | P = 0.23 | G2: 1 (0.3)
| | Fetal biparietal diameter, median (IQ range) | RR = 0
| | G1: 90 (87, 92) | P = 0.45
| | G2: 91 (88, 96) | Anaemia, N (%)
| | P < 0.001 | G1: 35 (9.1)
| | N of previous cesareans | G2: 31 (9.7)
| | NR | RR = 0.94 (0.59–1.49)
| | Diabetes | P = 0.79
| | NR | Pulmonary embolism, N (%)
| | Gestational age, median wks (IQ range) | G1: 0
| | G1: 38 4/7 (37 5/7, 39 2/7) | G2: 1 (0.3)
| | G2: 38 1/7 (37 6/7, 39 0/7) | RR = NR
| | P = 0.02 | P = 0.45
| | Type of labor | Cardiorespiratory arrest, N (%)
| | NR | G1: 0
| | Type of anesthesia | G2: 2 (0.6)
| | NR | RR = NR
| | Fetal weight, estimated gms, median (IQ range) | P = 0.21
| | G1: 3000 (2800, 3300) | Total maternal morbidity, N (%)
| | G2: 3300 (3000, 2500) | G1: 68 (17.7)
| | P < 0.001 | G2: 90 (28.1)
| | | RR = 0.063 (0.48–0.83)
| | | P = 0.001
Author | Objective of the study | Maternal age, N ≥ 35 yrs (%) | Major puerperal infection (incidence/100) | NR | Relevance
Koroukian 2004 | To estimate the relative risk of postpartum complications by type of delivery among Ohio Medicaid beneficiaries | G1: 4067 (2.95) | G1a: 0.90 | | Low
Setting | Definition of elective cesarean | G2: 1416 (4.56) | G1a*: 0.83 | | Quality Rating
US, population-based | Performed between 37 and 42 wks GA, birthweight between 2500–4000 gms, in the absence of any documented maternal medical risk factors, or labor and delivery events in the birth certificate | Maternal BMI | G1b: 1.11 | | Not rated
Study design | Probably includes some women in labor | NR | G2a: 4.28
Retrospective cohort | Modes of delivery other than elective c/d include | Parity | G2b: 2.87
Inclusion criteria | - Febrile condition; - Meconium; - PROM; - Placenta previa; - Abruptio placenta; - Other excessive bleeding; - Seizures during labor; - Precipitous labor; - Prolonged labor; - Dysfunctional labor; - Breech malpresentation; - Cephalopelvic disproportion; - Cord prolapse; - Anesthetic complications; - Fetal distress; - Other labor and delivery events | NR | RR for G2 vs G1: 4.07 (3.71–4.46)
- Participaition in the Ohio Medicaid fee-for-servuce system; - Continuous eligibility for Medicaid for 60 days PP | | N of previous cesareans | RR for G2b vs G1a*: 3.75 (3.12–4.51)
Exclusion criteria | | NR | Thromboembolic events (incidence/100)
- Multiple births; - Women with disabling conditions identified through eligibility for the Medicaid blind and disabled program | | Diabetes, N (%) | G1a: 0.07
Groups | | G1: 2512 (1.82) | G1a*: 0.06
G1: Vaginal delivery | | G2: 1319 (4.25) | G1b: 0.11
G1a: Spontaneous vaginal delivery | | Gestational age | G2a: 0.45
- G1a*: Uncomplicated vaginal delivery (appears to be a subset of G1a); - G1b: Assisted vaginal delivery | | NR | G2b: 0.19
G2: C/d | | Type of labor | RR for G2 vs G1: 4.07 (3.02–5.48)
- G2a: Nonelective c/d; - G2b: Elective c/d | | NR | RR for G2b vs G1a*: 3.45 (1.70–7.00)
N | | Type of anesthesia | Anesthetic complications (incidence/100)
G1a: 120,107 | | NR | G1a: 0.09
G1b: 17,595 | | Fetal weight | G1a*: 0.09
G1a*: 60,765 | | NR | G1b: 0.16
G2a: 25,641 | | | G2a: 0.36
G2b: 5,393 | | | G2b: 0.39
| | | RR for G2 vs G1: 3.64 (2.79–4.76)
| | | RR for G2b vs G1a*: 4.43 (2.68–7.34)
| | | Postpartum hemorrhage (incidence/100)
| | | G1a: 3.00
| | | G1a*: 2.42
| | | G1b: 3.13
| | | G2a: 2.22
| | | G2b: 1.74
| | | RR for G2 vs G1: 0.51 (0.46–0.56)
| | | RR for G2b vs G1a*: 0.60 (0.48–0.76)
| | | Transfusion (incidence/100)
| | | G1a: 0.11
| | | G1a*: 0.06
| | | G1b: 0.12
| | | G2a: 0.37
| | | G2b: 0.07
| | | RR for G2 vs G1: 1.86 (1.38–2.52)
| | | RR for G2b vs G1a*: 1.16 (0.41–3.25)
| | | Obstetric trauma (incidence/100)
| | | G1a: 7.35
| | | G1a*: 6.94
| | | G1b: 7.05
| | | G2a: 0.57
| | | G2b: 1.09
| | | RR for G2 vs G1: 0.09 (0.07–0.11)
| | | RR for G2b vs G1a*: 0.16 (0.16–0.20)
| | | Obstetric surgical wound complication (incidence/100)
| | | G1a: 0.25
| | | G1a*: 0.25
| | | G1b: 0.49
| | | G2a: 3.61
| | | G2b: 3.00
| | | RR for G2 vs G1: 12.10 (10.69–13.69)
| | | RR for G2b vs G1a*: 12.50 (10.00–15.63)
Author | Objective of the study | Maternal age, N (%) | Hemorrhage and/or anemia, N (%) | Hospitalization with vaginal descensus or urine incontinence, N (%) | Relevance
Krebs and Langhoff-Roos, 2003 | To compare the maternal complications of elective c/d for breech at term with those after vaginal or emergency c/d | < 20: | G1: 430 (5.7) | G1: 42/7,503 (0.6) | Low
Setting | Definition of elective cesarean | G1: 215 (2.9) | G2: 142 (6.0) | G2: 13/2363 (0.6) | Quality Rating
Denmark, population-based | Excludes labor | G2: 96 (4.1) | G3: 393 (7.0) | G3: 80/5575 (0.5% as reported in article, 1.4% as calculated by authors of this report) | Not rated
Study design | Category includes: | G3: 232 (4.2) | RR for G1 vs G2: 1.0 (0.94 – 1.03) | NS
Retrospective cohort | - Hypertension; - Diabetes; - Fetal death before onset of labor | P < .01 for G2 vs G1 | RR for G1 vs G3: 0.91 (0.84–0.97 | Hospitalization for fistula or anal incontinence:
Inclusion criteria | | P < .001 for G3 vs G1 | Puerperal fever/Pelvic Infection, N (%) | G1: 0
- Singleton; - Term; - Breech; - Delivery in Denmark; - 1982-1995 | | ≥ 35 | G1: 110 (1.5) | G2: 0
Exclusion criteria | | G1: 436 (5.8) | G2: 12 (0.5) | G3: 0
- NR | | G2: 50 (2.1) | G3: 126 (2.3) | Notes: All outcomes for second or third pregnancy by mode of delivery in first pregnancy
Groups | | G3: 217 (3.9) | RR for G1 vs G2: 1.2 (1.11–1.25) | Placenta Previa, N (%)
G1: Elective c/d | | P < .001 for G2 vs G1, G3 vs G1 | RR for G1 vs G3: 0.81 (0.7–0.92) | G1: 5 (0.1)
G2: Vaginal | | Maternal BMI | Wound infection, N (%) | G2: 1 (0.06)
G3: Emergency c/d | | NR | G1: 65 (0.9) | G3: 3 (0.08)
N | | Gravidity | G2: 16 (0.7) | RR for G1 vs G2: 1.14 (0.61–1.35)
G1: 7,503 | | NR | G3: 98 (1.8) | RR for G1 vs G3: 1.12 (0.52–1.60)
G2: 2,363 | | N of previous cesareans | RR for G1 vs G3: 0.69 (0.57–0.83) | Abruptio, N (%)
G3: 5,575 | | NR | Bladder injury, N (%) | G1: 19 (0.4)
Follow-up | | Diabetes, N (%) | G1: 5 (0.1) | G2: 6 (0.3)
5–18 years after first delivery | | G1: 59 (0.8) | G2: 0 | G3: 25 (0.6)
| | G2: 7 (0.3) | G3: 10 (0.2) | RR for G1 vs G2: 1.04 (0.78–1.22)
| | G3: 17 (0.3) | RR for G1 vs G3: 0.58 (0.23–1.02) | RR for G1 vs G3: 0.77 (0.52–1.04)
| | P < .01 for G2 vs G1 | Thromboembolism, N (%) | Future Ob/Gyn Issues, N (%)
| | P < .001 for G3 vs G1 | G1: 6 (0.1) | Subsequent delivery
| | Gestational age | G2: 0 | G1: 4126 (55.0)
| | All term | G3: 7 (0.1) | G2: 1451 (61.4)
| | Type of labor | RR for G1 vs G2: 1.31 (0.95–1.32) | G3: 3270 (58.7)
| | NR | RR for G1 vs G3: 0.80 (0.38–1.26) | RR for G1 vs G2: 0.94 (0.92–0.96)
| | Type of anesthesia | Rupture of the anal sphincter, N (%) | RR for G1 vs G3: 0.94 (0.91–0.97)
| | NR | G1: 0 | Admissions for infertility
| | Fetal weight, N (%) | G2: 41 (1.7) | G1: 79 (1.1)
| | < 2500 gms | G3: 0 | G2: 23 (1.0)
| | G1: 231 (3.1) | | G3: 61 (1.1)
| | G2: 117 (5.0) | | Ectopic pregnancy
| | G3: 307 (5.5) | | G1: 184 (2.5)
| | P < .001 for G2 vs G1, G3 vs G1 | | G2: 66 (2.8)
| | >4000 gms | | G3: 144 (2.6)
| | G1: 520 (6.9) | | Hospitalization for miscarriage
| | G2: 47 (2.0) | | G1: 508 (6.8)
| | G3: 334 (6.0) | | G2: 167 (7.1)
| | P < .001 for G2 vs G1 | | G3: 409 (7.3)
| | P < .05 for G3 vs G1 | | Fecundity (proportion of women having a second birth) for low risk mothers < 30, without diabetes, HTN, or perinatal death at first delivery, N (%)
| | Other: | | G1: 3296 (61)
| | Medical conditions | | G2: 1204 (64)
| | HTN, N (%): | | G3: 2682 (64)
| | G1: 293 (3.9) | | RR for G1 vs G2: 0.93 (0.91–0.96)
| | G2: 56 (2.4) | | RR for G1 vs G3: 0.91 (0.88–0.95)
| | G3: 219 (3.9) | | Preterm delivery < 37 wks
| | P < .001 for G2 vs G1, G3 vs G1 NS | | G1: 177 (3.6)
| | Smoker (%) | | G2: 101 (5.6)
| | G1: 29.9 | | G3: 242 (6.2)
| | G2: 29.4 | | RR for G1 vs G2: 0.86 (0.78–0.94)
| | G3: 30.5 | | RR for G1 vs G3: 0.75 (0.66–0.83)
| | Characteristics of Delivery Technique (%) | | Fetal death before onset of labor
| | G1: NA | | G1: 11 (0.2)
| | G2: | | G2: 5 (0.2)
| | - Forceps: 5.1; - Episiotomy: 47.6 | | G3: 11 (0.3)
| | G3: NR | | RR for G1 vs G2: 0.94 (0.61–1.19)
| | | | RR for G1 vs G3: 0.90 (0.54–1.25)
| | | | Intrapartum death
| | | | G1: 3 (0.06)
| | | | G2: 1 (0.06)
| | | | G3: 4 (0.1)
| | | | RR for G1 vs G2: 1.02 (0.38– 1.34)
| | | | RR for G1 vs G3: 0.77 (0.23–1.38)
| | | | 5-min Apgar < 7
| | | | G1: 58 (1.1)
| | | | G2: 20 (1.1)
| | | | G3: 50 (1.2)
| | | | RR for G1 vs G2: 1.01 (0.87–1.14)
| | | | RR for G1 vs G3: 0.96 (0.79–1.23)
| | | | Early neonatal death
| | | | G1: 19 (0.4)
| | | | G2: 4 (0.2)
| | | | G3: 11 (0.3)
| | | | RR for G1 vs G2: 1.13 (0.87–1.29)
| | | | RR for G1 vs G3: 1.13 (0.82–1.42)
Author | Objective of the study | Maternal age median yrs ± SD | NR | New anal incontinence, N (%) | Relevance
Lal et al., 2003 | To compare the incidence and severity of anal incontinence in primiparas after cesarean delivery versus spontaneous vaginal delivery | G1: 28.2 ± 5 | | G1: 6/104 (5.8) | Moderate
Setting | Definition of elective cesarean | G2: 28.8 ± 5 | | G2: 3/80 (3.8) | Quality Rating
UK, hospital-based | Planned procedure or immediately after the onset of labor in anyone due for a planned delivery | G3: 27.5 ± 4 | | G3: 8/100 (8) | Fair
Study design | Does not include labored births | Maternal BMI | | Anal incontinence severe enough to require pad use, N (%)
Prospective cohort | Category includes: | NR | | G1: 0
Inclusion criteria | Fetal distress | Gravidity | | G2: 2/80 (2.5)
- Consecutive primiparas with live singleton pregnancies between April 1997 and Sept 1998 | G1: 53 | NR | | G3: 1/100 (1)
Exclusion criteria | G2: 0 | N of previous cesareans | | Authors also compare c/d not in labor (emergency + elective) to vaginal delivery and find that the difference is not statistically significant
- Pregnant again; - Had an operation, severe psychiatric or medical problem, neurologic problem, urinary tract anomaly, or diversion, ill infant | G3: NA | NR
Groups | Breech | Diabetes
G1: Emergency c/d | G1: 10 | G1: 0
G2: Elective c/d | G2: 48 | G2: 2
G3: Vaginal delivery (non instrumental) | G3: NA | G3: NR
N retained | Preeclampsia | Gestational age, median wks (range)
G1: 104 | G1: 5 | G1: 39 (27–41)
G2: 84 | G2: 5 | G2: 38 (27–41)
G3: 100 | G3: NA | G3: 39 (32–41)
| Failure to progress | Type of labor
| G1: 27 | NR
| G2: 0 | Type of anesthesia
| G3: NA | NR
| Cephalopelvic disproportion | Fetal weight, kg, ± SD
| G1: 0 | G1: 3.1 ± 0.7
| G2: 12 | G2: 3.1 ± 0.7
| G3: NA | G3: 3.2 ± 0.4
| Fetal growth restriction | Urinary incontinence before pregnancy, N (%)
| G1: 0 | NR
| G2: 3 | Maternal race (N)
| G3: NA | White
| Maternal request | G1: 98
| G1: 0 | G2: 77
| G2: 3 | G3: 96
| G3: NA | Asian
| Miscellaneous | G1: 3
| G1: 9 | G2: 2
| G2: 9 | G3: 4
| G3: NA | Afro-Caribbean
| | G1: 3
| | G2: 1
| | G3: 0
| | Maternal age
| | NR
| | Maternal BMI
| | NR
| | Gravidity
| | NR
| | N of previous cesareans
| | NR
| | Diabetes
| | NR
| | Gestational age
| | NR
| | Type of labor
| | Induced labor
| | G1: NR
| | G2: NR
| | G3: 16
| | Type of anesthesia
| | NR
| | Fetal weight, mean kg ± SD
| | G1: 3.1 ± 0.7
| | G2: 3.1 ± 0.7
| | G3: 3.2 ± 0.4
| | Urinary incontinence before pregnancy
| | NR
| | Maternal medical condition:
| | Irritable Bowel Syndrome
| | G1: 10
| | G2: 4
| | G3: 6
| | Time to delivery
| | Not in labor
| | G1: 21
| | G2: 80
| | G3: NA
| | Early labor (cervix < 8 cm)
| | G1: 63
| | G2: 0
| | G3: NA
| | Late labor (cervix > 8 cm)
| | G1: 20
| | G2: NA
| | G3: NA
| | Mean
| | Fetal head circumference, mean cm ± SD
| | G1: 34 ± 4
| | G2: 35 ± 3
| | G3: 34 ± 2
Author | Objective of the study | Maternal age | Maternal morbidity (temperature > 38 at 2 or more days PP, endometritis, wound infection, UTI, thrombophlebitis | NR | Relevance
Leiberman et al., 1995 | To examine pregnancy outcome in nulliparous women with single term breech presentation | NR | G1: 24/135 | | T
Setting | Definition of elective cesarean | Maternal BMI | G2: 40/129 | | Quality Rating
Israel hospital (2 Depts of Ob/Gyn that differ in their management to breech) | Includes labored births, number NR | NR | OR = 0.48 (0.25–0.89) | | Fair
Study design | Category includes: | Gravidity | P = 0.01
Prospective Cohort | - Placenta previa; - Fetal anomalous presentation | NR
Inclusion criteria | | N of previous cesareans
- Nulliparous; - Frank breech | | NR
Exclusion criteria | | Diabetes
- Multiparity; - Preterm; - Complete or footling breech; - Multiple gestation; - Antepartum death; - Major congenital malformations | | NR
Groups | | Gestational age
G1: Planned trial of labor | | NR
G2: Planned c/d | | Type of labor
N at assignment | | NR
G1: 135 | | Type of anesthesia
G2: 129 | | NR
| | Fetal weight
| | NR
Author | Objective of the study | Maternal age, mean yrs ± SD | NR | Fecal incontinence, N (%) | Relevance
MacArthur, Bick, and Keighley, 1997 | To measure the prevalence and severity of postpartum fecal incontinence, especially new incontinence and to identify obstetric risk factors | G1a: 27.9 yrs ± 5.5 | | Elective | Low
Setting | Definition of elective cesarean | G1b: 30.9 yrs ± 4.8 | | Total: 0/61 (0) | Quality Rating
UK, hospital-based | Probably includes labored births, number NR. | G2a: 26.7 ± 5.2 | | Primip: 0/13 (0) | Not rated
Study design | Category not specified | G2b: 29.6 ± 4.6 | | Multip: 0/48 (0)
Case-control | | Maternal BMI | | Emergency
Inclusion criteria | | NR | | Total: 6/113 (5.3)
- Women who had postpartum symptoms (backache, headaches, neckache, paraesthesias in hands, pain legs, visual disturbances, dizziness or fainting, stress incontinence, fatigue, fecal incontinence, sexual problems, and depression and randomly selected women without symptoms | | Gravidity, N (%) | | Primp: 5/59 (8.5)
Exclusion criteria | | One | | Multip: 1/54 (1.9)
- NR | | G1a: NR | | Forceps
Groups | | G1b: 10 (65.6) | | Total: 8/110 (7.2)
G1a: Primiparous, new incontinence | | G2a: NR | | Primp: 5/86 (5.8)
G1b: Multiparous, new incontinence | | G2b: 305 (61.5) | | Multip: 3/24 (12.5)
G2a: Primiparous, never had incontinence | | Two | | Vacuum
G2b: Multiparous, never had ncontinence | | G1a: NR | | Total: 4/18 (22.2)
Each group further divided into elective, emergency, forceps, vacuum, spontaneous, vaginal | | G1b: 7 (38.9) | | Primp: 3/14 (21.4))
N | | G2a: NR | | Multip: 1/4 (25.0)
Contacted for interview at 45 wks | | G2b:115 (23.2) | | Spontaneous vaginal delivery
PP: 1,156 | | ≥ Three | | Total: 18/568 (3.2)
Interviewed: 906 | | G1a: NR | | Primp: 5/189 (2.6)
N for analysis | | G1b: 1 (5.6) | | Multip: 13/379 (3.4)
Elective: 61 | | G2a: NR
Emergency: 113 | | G2b: 76 (15.3)
Forceps: 110 | | N of previous cesareans
Vacuum: 18 | | NR
Spontaneous vaginal: 568 | | Diabetes
Total: 870 | | NR
| | Gestational age
| | NR
| | Type of labor, N (%)
| | Induced onset of labor
| | G1a: 5 (27.8)
| | G1b: 3 (16.7)
| | G2a: 49 (14.2)
| | G2b: 42 (8.5)
| | Type of anesthesia
| | NR
| | Fetal weight, mean gms ± SD
| | G1a: 3306 ± 804.7
| | G1b: 3444 ± 435.4
| | G2a: 3318 ±861.3
| | G2b: 3432 ± 633.5
| | Fetal head circumference, mean cm ± SD
| | G1a: 34 ± 2.3
| | G1b: 34.6 ± 1.2
| | G2a: 34.5 ± 2.7
| | G2b: 34.7 ± 2.5
| | Second or greater perineal tear, N (% of new incontinence primiparous)
| | G1a: 5 (27.8)
| | G1b: 5 (27.8)
| | G2a: 91 (26.4)
| | G2b: 113 (22.8)
| | First stage of labor ≥ 10 hrs (% of new incontinence primiparous)
| | G1a: 9 (60.0)
| | G1b: 4 (22.2)
| | G2a: 136 (47.1)
| | G2b: 79 (19.8)
| | Second stage of labor ≥ 2 hrs (% of new incontinence primiparous)
| | G1a: 7 (38.9)
| | G1b: NR
| | G2a: 99 (28.5)
| | G2b: 24 (4.8)
| | Active second stage of labor ≥ 2 hrs (% of new incontinence primiparous)
| | G1a: 4 (22.2)
| | G1b: NR
| | G2a: 41 (11.8)
| | G2b: 19 (3.8)
Author | Objective of the study | NR | NR | Fecal Incontinence at 3 mos PP, % | Relevance
MacArthur, Glazener, and Wilson, 2001 | To determine whether obstetric and maternal factors relate to fecal incontinence at three months PP | | | All Women | Low
Setting | Definition of elective cesarean | | | G1:9.6 | Quality Ratings
UK, Hospital | NR | | | G2: 13.6 | Not rated
Study design | | | | G3: 10.3
Cross Sectional | | | | G4: 13.8
Inclusion criteria | | | | G5: 7.3
- All women | | | | G6: 7.5
Exclusion criteria | | | | Primiparae
- NR | | | | G1: 8.8
Groups | | | | G2: 13.9
G1: SVD | | | | G3: 9.3
G2: Forceps | | | | G4: 12.0
G3: Vacuum | | | | G5: 5.4
G4: Breech | | | | G6:4.8
G5: Elective c/d | | | | Multiparae
G6:Emergency c/d | | | | G1: 10.0
N | | | | G2: 12.2
G1: 4,963 | | | | G3: 14.3
G2: 654 | | | | G4: 15.0
G3: 329 | | | | G5: 8.0
G4: 65 | | | | G6:12.3
G5: 496
G6: 664
Author | Objective of the study | Maternal age, N (%) | Stress urinary incontinence, N (%) | NR | Relevance
Mason et al., 1999 | To undertake a prospective survey of the prevalence of stress incontinence during pregnancy and following childbirth | < 20: | G1: 125/358 (34.9) | | Low
Setting | Definition of elective cesarean | 34/717 (4.8) | G2: 7/44 (15.9) | | Quality Rating
England, hospital-based | Unspecified | 20–29: | G3: 7/41 (17.1) | | Not rated
Study design | | 357/717 (49.8) | G4: 9/28 (32.1)
Prospective cohort | | 30–39: | G5: 11/27 (40.1)
Inclusion criteria | | 304/717 (42.3) | G1 vs G4: or G5: NS
- Consented to participate at prenatal visit; - 34 wks pregnant (Questionnaire 1); - 8 mos postpartum (Questionnaire 2) | | ≥ 40: | G2 vs G3: NS
Exclusion criteria | | 22/717 (3) | G1 vs G2 and G3 (cesarean):X^2^ = 10.85, P = 0.0009
- If any doubt that still pregnant; - Miscarriage/stillbirth/ neonatal death; - Birth outcome unknown to team | | Maternal BMI
Groups | | NR
G1: Vaginal delivery | | Parity, N (%)
G2: Planned c/d | | Nullip: 316/717 (44)
G3: Emergency c/d | | ≥ Para 1: 401/717 (56)
G4: Forceps | | N of previous cesareans
G5: Ventouse | | NR
N at enrollment | | Diabetes
At 34 wks of pregnancy: 717/918 | | NR
Response rate = 78% | | Gestational age
Follow-up at 8–10 wks PP | | NR
G1: 358/571 | | Type of labor
G2: 44/571 | | NR
G3: 41/571 | | Type of anesthesia
G4: 28/571 | | NR
G5: 27/571 | | Fetal weight
Total N at 8 wks PP = 572/894 | | NR
Response rate = 64% | | Urinary Incontinence, N (%)
| | At 34 weeks GA: 419/717 (59)
| | At 8 wks PP: 179/572 (31)
| | Extent of reported SUI at 34 weeks GA, N (%)
| | Daily leak of several time/wk: 207/419 (49.4)
| | Pad daily or most days: 46/419 (11)
| | Change underwear most or everyday (38/419 (9.1)
| | Onset of SUI measured at 34 weeks GA, N (%)
| | Symptoms began before any pregnancy: 25/419 (6)
| | During this pregnancy: 264/419 (63.0)
| | Symptoms began in connection to prior pregnancy or delivery: 127/419 (30)
Author | Objective of the study | Maternal age | Wound complications (“infection”) | NR | Relevance
Nice et al., 1996 | To determine the cesarean rates, wound infection rates, and whether any procedures or prophylactic antibiotics influenced the outcome | NR | G1: 14/220 | | Moderate
Setting | Definition of elective cesarean | Maternal BMI | G2: 31/408 | | Quality rating
UK, community-based hospital | Planned by obstetrician in antenatal clinic and performed at scheduled time or sooner if onset of labor accelerated time of delivery, as compared to emergency c/d which is performed for immediate or compelling clinical reasons and not planned in advance | NR | P= NS | | Poor
Study design | Includes labored births, number NR, indications for c/d unspecified | Gravidity
Prospective cohort | | NR
Inclusion criteria | | N of previous cesareans
- All c/d at 5 hospitals in 3 month period | | NR
Exclusion criteria | | Diabetes
- NR | | NR
Groups | | Gestational age
G1: Elective c/d | | NR
G2: Emergency c/d | | Type of labor
N at start of study | | NR
G1: NR | | Type of anesthesia
G2: NR | | NR
Follow-up | | Fetal weight
10 days for all patients who had c/d | | NR
G1: 220
G2: 408
Author | Objective of the study | Maternal age (yrs at 1st birth) | NR | Stress Urinary Incontinence Surgery | Relevance
Persson, Wølner-Hanssen, and Rhydstroem, 2000 | To evaluate obstetric and maternal risk factors for stress urinary incontinence | ≤ 19 | | OR for elective cesarean vs. non-instrumental vaginal singleton births among primiparous women: 0.21 (95% 0.13–0.34) | Low
Setting | Definition of elective cesarean | G1: 146 | | OR for any cesarean vs. non-instrumental vaginal delivery: 0.34 (95% CI 0.23–0.52) | Quality rating
Sweden, population-based | Undefined, probably includes labored births, number NR | G2: 74,459 | | | Not rated
Study design | | 20–24
Case-control | | G1: 598
Inclusion criteria | | G2: 334,156
- Females born 1932 to 1977 in Sweden who had surgery for stress urinary incontinence between 1987 and 1996; - For women who had more than 1 operation for stress incontinence, only 1st event of surgery was included | | 25–29
Exclusion criteria | | G1: 755
- Women born outside of Sweden; - Women who had first delivery < 1973; - Women who had been operated on before their 1st delivery; - Women who had unknown or absurd birth weight, or erroneous yr of delivery | | G2: 357,123
Groups | | 30–34
G1: Women who had surgery for stress urinary incontinence (1987 to 1996) | | G1: 329
G2: All women in population who met inclusion/exclusion criteria | | G2: 117,206
N at enrollment | | 35–39
G1: 1942 | | G1: 107
G2: 876,768 | | G2: 29,430
Follow-up | | 40–44
NR | | G1: 7
| | G2: 4,273
| | ≥ 45
| | G1: 0
| | G2: 121
| | Maternal BMI
| | NR
| | Parity
| | 1
| | G1: 336
| | G2: 251,027
| | 2
| | G1: 949
| | G2: 412,984
| | 3
| | G1:499
| | G2: 164,102
| | 4
| | G1: 113
| | G2: 37,639
| | ≥ 5
| | G1: 46
| | G2: 11,016
| | N of previous cesareans
| | NR
| | Diabetes
| | NR
| | Gestational age
| | NR
| | Type of labor
| | NR
| | Type of anesthesia
| | NR
| | Fetal weight
| | NR
Author | Objective of the study | Maternal age, mean yrs ± SD | Bladder injury | NR | Relevance
Phipps et al., 2005 | To identify risk factors for bladder injury during cesarean delivery | G1: 33.6 ± 3.7 | Scheduled c/d | | Low
Setting | Definition of elective cesarean | G2: 29.3 ± 6.3 | G1: 14% | | Quality rating
US, hospital-based | Scheduled surgery | Maternal BMI ± SD | G2: 27% | | Not rated
Study design | All groups include: | G1: 29.9 ± 5.4 | Urgent c/d
Case-control | - Previous cesarean deliveries; - Preterm deliveries | G2: 33.0 ± 6.7 | G1: 55%
Inclusion criteria | | Parity %, | G2: 62%
- All women who underwent c/d at Women and Infant's Hospital during study period (1/95 to 12/02) | | Nulliparous | Emergency c/d
Cases | | G1: 21 | G1: 31%
- Women with bladder injury Controls; - Two random controls per case | | G2: 48 | G2: 11%
Exclusion criteria | | Multiparous (≥1) | P = 0.01
- NR | | G1: 79
Groups | | G2: 52
G1: Cesarean delivery-elective and nonelective, primary and repeat with bladder injury | | N of previous cesareans
G2: Cesarean delivery, no bladder injury | | 0
Data reported for scheduled, urgent, emergency c/d for cases and controls | | G1: 33
N | | G2: 68
G1: 42 | | 1
G2: 84 | | G1: 43
| | G2: 27
| | ≥2
| | G1: 24
| | G2: 5
| | Diabetes
| | NR
| | Gestational age, mean wks ± SD
| | G1: 38.5 ± 1.9
| | G2: 37.5 ± 3.4
| | Type of labor (%)
| | Presence of labor
| | G1: 83
| | G2: 61
| | Type of anesthesia
| | NR
| | Fetal weight
| | NR
Author | Objective of the study | Maternal age, mean yrs (range) | NR | [underlined: Physiologic Mode] Woman's goals achieved | Relevance
Reichert, Baron, and Fawcett, 1993 | To compare findings of three studies of women's responses to planned and unplanned cesarean birth | G1: 29 (22–39) | | Unplanned: 43 | Low
Setting | Definition of elective cesarean | G2: 29.7 (25–37) | | Planned: 49 | Quality Rating
US, hospital-based | Labored births, number NR | G3: 31.5 (19–44) | | Not achieved | Not rated
Study design | Groups (each includes both elective and emergency cesarean deliveries) include: | Maternal BMI | | Unplanned: 134
Retrospective cohort | G1: | NR | | Planned: 94
Inclusion criteria | - Cephalopelvic disproportion (63%); - Dystocia (17%); - Fetal distress (8%); - Placenta previa (4%); - Toxemia (4%); - Genital herpes (4%) | Primipara | | [underlined: Self concept mode]
- Cesarean delivery; - Married/living with partner; - Full term deliveries; - English | G2: | G1: 17/24 | | Woman's goals achieved
Exclusion criteria | - Dystocia (40%); - Breech presentation (20%); - Cephalopelvic (13%); - Fetal distress (13%); - Purse string suture of the cervix (7%); - Previous myomectomy (7%) | G2: 15/15 | | Unplanned: 145
- NR | G3: | G3: 93/173 | | Planned: 154
Groups | - Previous c/d (27%); - Breech presentation (19%); - Cephalopelvic (19%); - Combination of factors (15%); - Failed induction (2%); - Other reasons (failed vaginal birth after c/d, failed forceps delivery, genital herpes) (3%) | Planned c/d | | Not achieved
G1: Cesarean deliveries, in 1973-80 | | Primiparas | | Unplanned: 113
G2: All deliveries, in 1981-82 | | G1: 4/17 | | Planned: 94
G3: All deliveries, in 1989-90 | | G2: 6/15 | | [underlined: Role function mode]
G3 further subdivided into planned and unplanned, outcomes listed for G3 alone | | G3: 12/93 | | Woman's goals achieved
N at enrollment | | Multiparas | | Unplanned: 10
G1: 24 | | G1: 7/7 | | Planned: 4
G2: 15 | | G2: NA, no multiparas | | Not achieved
G3: 173 | | G3: 72/80 | | Unplanned: 22
Planned: 84 | | Diabetes | | Planned: 10
Unplanned: 89 | | NR | | [underlined: Interdependence mode*]
Follow-up | | Gestational age | | Woman's goals achieved
G1: From a few months to 6 years | | NR | | Unplanned: 47
G2: 6 weeks PP | | Type of labor | | Planned: 33
G3: 6 weeks PP | | NR | | Ineffective mode
| | Type of anesthesia | | Unplanned: 30
| | NR | | Planned: 17
| | Fetal weight | | Test of effective vs. iNot achieveds by planned vs. unplanned cesarean for Group 3:
| | NR | | X^2^ = 5.59, P = 0.0173
| | | | Test of effective vs. iNot achieveds by planned vs. unplanned for Group 1 (data NR):
| | | | X^2^ = 13.12, P = 0.0006
| | | | Test of effective vs. iNot achieveds by planned vs. unplanned for Group 2 (data NR, X^2^ NR)
| | | | NS
| | | | *See article for description of items within each mode; too lengthy to include here
Author | Objective of the study | Maternal age, mean yrs | Median post-traumatic stress reactions measured by Impact of Event Scale (range) | NR | Relevance
Ryding, Wijma, and Wijma, 1998 | To compare the psychological reactions of women after different modes of delivery | G1: 31 | 2 days PP | | Low
Country, Setting | Definition of elective cesarean | G2: 30 | G1: 10.8 (4.0–21.8) | | Quality Rating
Sweden, hospital-based | Includes women who had had a date set for elective delivery but were operated on as an emergency procedure because of the onset of labor | G3: 28 | G2: 6.0 (3.0–12.0) | | Not rated
Study design | Includes labored births, but number | G4: 28 | G3: 13.0 (5.0–18.3)
Prospective cohort | NR | All groups: 29 | G4: 10.0 (4.0–16.8)
Inclusion criteria | | Maternal BMI | G1 vs G2: P = 0.001
- Swedish speaking; - Women subjected to cesarean delivery; - Instrumental vaginal delivery or normal vaginal delivery; - Delivered live child | | NR | 1 month PP
Exclusion criteria | | Primiparous, % | G1: 8.0 (3.8–15.0)
- Transferred to another hospital; - Randomly selected for different study and excluded from this study (n = 53); - Artificial rupture of membranes; - Oxytocin stimulation of spontaneous labor | | G1: 34 | G2: 5.0 (1.0–11.0)
Groups | | G2: 58 | G3: 9.0 (5.0–18.6)
- G1: Emergency cesarean; - G2: Elective cesarean; - G3: Instrumental vaginal delivery; - G4: Normal vaginal delivery | | G3: 87 | G4: 6.0 (3.0–11.0)
N at few days PP | | G4: 52 | G1 vs G2: P < 0.01
G1: 75 | | All Groups: 58 | Median mental distress measured by subset of Symptoms Check List (range)
G2: 79 | | N of previous cesareans | 2 days PP
G3: 104 | | NR | G1: 19.0 (10.2–30.0)
G4: 104 | | Diabetes | G2: 16.0 (10.1–21.5)
Follow-up | | NR | G3: 20.0 (10.0–33.8)
1 month PP | | Gestational age | G4: 11.1 (6.0–17.0)
- G1: 71; - G2: 70; - G3: 96; - G4: 96 | | NR | G1 vs G2: P < 0.05 on anxiety only
| | Type of labor | 1 month PP
| | NR | G1: 13.0 (7.0–23.0) NS
| | Type of anesthesia | G2: 11.0 (6.0–17.0)
| | NR | G3: 15.0 (5.8–28.3) NS
| | Fetal weight | G4: 14.0 (4.5–19.5) NS
| | NR | G1 vs G2: P = NS
| | | Median appraisal of delivery measured by Vaginal Delivery Expectancy Questionnaire
| | | 2 days PP
| | | G1: 59.3 (47.8–68.8)
| | | G2: 41.0 (31.0–51.0)
| | | G3: 52.0 (37.0–64.0)
| | | G4: 33.9 (28.5–45.0)
| | | G1 vs G2: P < .0001
| | | 1 month PP
| | | G1: 52.0 (40.5–64.8)
| | | G2: 32.3 (24.0–42.0)
| | | G3: 44.0 (31.5–53.5)
| | | G4: 26.0 (19.5–39.5)
| | | G1 vs G2: P < 0.01
| | | Change over time by groups were all statistically significant (P < 0.05 to P < .0001) for each type of questionnaire except for G2 for post -traumatic stress and G4 for mental distress
Author | Objective of the study | Maternal age, mean yrs ± SD | Length of stay, median days (interquartile range) | NR | Relevance
Sanchez-Ramos et al, 2001 | To compare maternal and neonatal outcomes in elective cesarean vs attempted vaginal delivery for breech presentation at or near term | G1: 24.2 ± 5.7 | G1: 2 (2, 3) | | Moderate
Setting | Definition of elective cesarean | G2: 24.0 ± 5.9 | G2: 4 (4, 4) | | Quality rating
US, hospital-based | Probably includes labored births, number NR | P = 0.62 | P = 0.001 | | Poor
Study design | Category includes: | Maternal BMI | Febrile morbidity, N (%)
Retrospective cohort | - Patient choice (40.8%); - Repeat (% NR); - Incomplete breech (25.0%); - Abnormal pelvimetry (10.1%); - Macrosomia (4.9%); - Hyperextension (3.3%); - Non-reassuring fetal testing (3.8%) | NR | G1: 23/272 (8.4)
Inclusion criteria | | Nulliparity, N (%) | G2: 79/576 (13.7)
- Singleton; - Breech; - Planned c/d offered; offered trial of labor if following criteria were met: singleton, frank or complete breech; EFW 2000 to 4000 g; adequate pelvis by exam or CT; non extended fetal head by U/S or CT | | G1: 122 (44.8%) | P = 0.03
Exclusion criteria | | G2: 265 (46%) | Hemorrhage, N (%)
- NR | | P = 0.81 | G1: 3/272 (1.1)
Groups | | Previous cesareans, N (%) | G2: 7/576 (1.2)
G1: Attempted vaginal breech | | G1: 16 (5.9) | P = 1.00
G2: Elective c/d | | G2: 92 (16%) | Anesthesia complications, N (%)
N | | P = 0.0003 | G1: 3/272 (1.1)
G1: 272 | | Diabetes | G2: 6/576 (1.0)
G2: 576 | | NR | P = 1.00
| | Gestational age, mean wks ± SD | No morbidity, N (%)
| | G1: 38.7 ± 1.9 | G1: 241/272 (88.6)
| | G2: 38.3 ± 2.4 | G2: 476/576 (82.6)
| | P = 0.03 | P = 0.02
| | Augmentation of labor via oxytocin, N (%)
| | G1: 106 (39)
| | G2: 4 (0.7)
| | P = 0.0001
| | Type of anesthesia
| | NR
| | Fetal weight estimated gms ± SD
| | G1: 3028 ± 522
| | G2: 3096 ± 687
| | P = 0.26
Author | Objective of the study | Maternal age, mean yrs (range) | Blood transfusion required, N (%) | NR | Relevance
Schindl et al., 2003 | To investigate birth experience and medical outcome in women with elective cesarean delivery compared with intended vaginal delivery | G1: 28 (15–43) | G1: 6/903 (0.6) | | Moderate
Setting | Definition of elective cesarean | G2a: 32 (20–44) | G2: 0 | | Quality rating
Austria, hospital-based | Probably includes labor, number NR | G2b: 30 17–44) | Sepsis, N (%) | | Fair
Study design | Elective c/d on demand includes: | P < 0.05 | G1: 1/903 (0.1)
Prospective cohort | - Anxiety, nulliparae (16/44); - Previous traumatic birth (20/44); - Other (coordination problems, safety considerations) (8/44) | Maternal BMI | G2: 0
Inclusion criteria | Elective c/d for medical indications includes: | NR | Perineal laceration III/IV, N (%)
- Gestation week 38 | - Breech (40/103); - Twins (7/103); - Preeclampsia (6/103); - CS interval < 15 mos (19/103); - Cephalopelvic disproportion (4/103); - HIV and hepatitis C (5/103); - Neurological problems (e.g., epilepsy) (10/103); - Internal problems (e.g., heart failure) (9/103); - Others (e.g., pelvic failure) (3/103) | N of previous births mean (range) | G1: 2/903 (0.2)
Exclusion criteria | | G1: 0 (0–9) | G2: 0
- < 19 yrs; - Inability to complete questionnaire; - Unwillingness to participate; - Severe internal problems (e.g., HELLP syndrome) | | G2a: 1 (0–5) | Labial, vaginal, perineal laceration I/II, N (%)
Groups | | G2b: 0 (0–3) | G1: 302/903 (33.4)
G1: Intended vaginal delivery | | N of previous cesareans | G2: 0
G2: Elective c/d | | NR | Complications of peridural anesthesia, N (%)
- G2a: Elective c/d (medical reasons) | | Diabetes | G1: 18/903 (2.0)
- G2b: Elective c/d (“on demand”) | | NR | G2: 6/147 (4.0)
N at enrollment | | Gestational age | Pain, VAS scale (results presented graphically in article)
G1: 903 | | NR | - At birth, significantly higher median pain level during birth in the vaginal or assisted vaginal delivery groups compared to the cesarean group (“peridural” anesthesia was offered to every woman but only chosen in 11% of patients; - At 3 days PP, pain significantly lower among spontaneous vaginal group compared to all C/d, no difference between c/d groups; - At 4 mos PP, no difference in momentary birth-related pain was observed between all groups (Kruskal-Wallis test, P = 0.192)
G2: 147 | | Type of labor | Birth experience, Zerrsen test for momentary personal feelings (results presented graphically in article)
- G2a: 103; - G2b: 44 | | NR | - Before birth, no differences in momentary personal feelings before birth; - At 3 days PP, women in the assisted vaginal delivery and emergency cesarean delivery groups experienced strong negative feelings; - At 4 mos PP, no difference between groups
Follow-up | | Type of anesthesia | Birth experience, modified version of Salmon and Drew's birth experience questionnaire (results presented graphically in article)
3 days PP | | NR | - Before birth, women planning a cesarean delivery without medical indications had an expectation of a more pleasant birth compared to women planning a vaginal delivery or a cesarean for medical indications; - At 3 days PP, most positive birth experiences in descending order: elective c/d on demand, elective c/d for medical indications, vaginal delivery, emergency c/d and assisted vaginal delivery
NR | | Fetal weight | At 4 mos PP, most positive birth experiences in descending order: elective c/d on demand, elective c/d for medical indications, vaginal delivery, emergency c/d and assisted vaginal delivery
4 mos PP | | NR
23.9% response rate | | Other
| | NR
Author | Objective of the study | Maternal age, mean yrs ± SD | NR | Stress incontinence at 1 yr PP, % | Relevance
Schytt, Lindmark, Waldenstrom, 2004 | To describe the prevalence of stress incontinence, as described by the women themselves, one year after childbirth in a national sample of Swedish-speaking women, and to identify possible predictors | Overall: 29.5 ± 4.6 | | Primiparas | Low
Setting | Definition of elective cesarean | Median: 29.0 | | G1: 0 | Quality Ratings
Western Europe, hospital-based | NR | Maternal BMI | | G2: 11.5 | Not rated
Study design | | NR | | RR: 0.6 (0.3–1.0)
Cross Sectional at 1yr PP | | Gravidity | | G3: 19.9
Inclusion criteria | | NR | | G4: 21.8
- Attending antenatal clinic | | N of previous cesareans | | RR: 1.1 (0.8–1.6)
Exclusion criteria | | NR | | Multiparas
- Miscarriages; - Non-Swedish speaking; - Twin deliveries | | Diabetes | | G1: 12.9
Groups | | NR | | RR: 0.5 (0.3–0.9)
G1: Elective c/d | | Gestational age | | G2: 12.7
G2: Emergency c/d | | NR | | RR: 0.5 (0.3–1.0)
G3: Vaginal | | Type of labor | | G3: 25.4
G4: Forceps & vacuum | | NR | | G4 38.5
N at 1 yr PP | | Type of anesthesia | | RR: 1.5 (1.0–2.3)
G1: 133 | | NR
G2: 185 | | Fetal weight, grams
G3: 1893 | | NR
G4 172 | | Urinary incontinence before pregnancy, N (%)
| | NR
| | Pregravida BMI ≥ 30
| | Primaparous: 25%
| | RR: 1.5(1.1–2.0)
| | Multiparous: 29.3%
| | RR: 1.3 (1.0–1.6)
| | Parity
| | Primiparous: 44%
| | Previous cesarean/s
| | Multiparous: 13%
| | Fetal weight, mean gms
| | > 4500
| | Primaparous: 17.9%
| | RR: 1.0 (0.4–2.3)
| | Multiparous: 23%
| | RR: 1.3 (0.8–2.0)
Author | Objective of the study | Maternal age, mean (range) | Thrombosis, N (%) | Maternal death | Relevance
van Ham, van Dongen, and Mulder, 1997 | To assess intraoperative surgical complications and postoperative maternal morbidity rate of cesarean delivery | G1: 30.5 (18–43) | G1: 4 (0.6) | G1: NR | Moderate
Setting | Definition of elective cesarean | G2: 28.9 (16–49) | G2: 9 (1.0) | G2: NR | Quality rating
Netherlands, hospital-based | Primary: planned operation, patient admitted ≥ 8 hrs before c/d without symptoms of ruptured membranes, regular uterine contractions or vaginal bleeding | G3: 29.3 (17–47) | G3: 3 (0.3) | G3: NR | Poor
Study design | | Maternal BMI | Total 16 (1.5) | Total: 3/2,647
Retrospective cohort | | NR | Thrombophlebitis, N (%) | Intra-operative complications, N (%)
Inclusion criteria | | Parity, mean (range) | G1: 8 (1.1) | G1: 65 (9.1) P < 0.001
- All c/d performed in the Dept of Ob/Gyn in University Hospital, Netherlands, between 1983 and 1992 | | G1: 1.0 (0–9) | G2: 16 (1.8) | G2: 77 (9.0)
Exclusion criteria | | G2: 0.7 (0–11) | G3: 41 (3.8) | G3: 250 (23.4) P < 0.001
- None | | G3: 0.4 (0–6) | Total: 65 (2.5) | Total: 392/2,647 (14.8)
Groups | | N of previous cesareans (repeat), N (%) | Pneumonia, N (%) | Uterine laceration, N (%)
G1: Primary elective c/d-planned operation, admitted 8 hr before c/d w/o symptoms of ruptured membranes, contractions, or bleeding (i.e., election) | | G1: 64 (8.9) P < 0.001 | G1: NR | G1: 43 (6.0)
G2: Primary acute c/d-time between decision to deliver abdominally and actual performance < 8 hr ignoring stage of labor, no attempt to deliver vaginally (i.e., c/d, unclear whether labored or not, emergency) | | G2: 23 (2.5) | G2: 5 (0.6) | G2: 47 (5.5)
G3: Secondary acute c/d - c/d following failed vaginal delivery (i.e., labored emergency c/d) | | G3: 15 (1.4) | G3: 4 (0.4) | G3: 176 (6.5) P < 0.001
N at selection | | Diabetes | Total: 9 (0.3) | Total: 226 (10.1)
G1: 718/2,647 | | NR | Fever, N (%) | Bladder lesion, N (%)
G2: 859/2,647 | | Gestational age, N (%) | G1: 113 (15.7) P < 0.001 | G1: 9 (1.3)
G3: 1,070/2,647 | | < 28 weeks | G2: 217 (25.3) | G2: 3 (0.4)
Follow-up | | G1: 5 (0.7) | G3: 322 (30.1) | G3: 10 (0.9)
NR | | G2: 51 (5.9) | Total: 652 (24.6) | Total: 22 (0.8)
| | G3: 10 (0.9) | Coagulation disorders, N (%) | Lesions of uterine arteries/ ligamentum latum/bowels, N (%)
| | 28–37 wks | G1: NR | G1: 3 (0.4)
| | G1: 95 (13.2) | G2: 1 (0.1) | G2: 5 (0.6)
| | G2: 52 (65.4) | G3: NR | G3: 6 (0.6)
| | G3: 115 (10.7) | Total: 1 (0.1) | Total: 14 (0.5)
| | > 37 wks | Ileus, N (%) | Cervical vaginal lesions, N (%)
| | G1: 618 (86.1) | G1: 8 (1.1) | G1: NR
| | G2: 246 (28.7) | G2: 18 (1.9) | G2: 2 (0.2)
| | G3: 945 (88.4) | G3: 14 (1.2) | G3: 6 (0.6)
| | Type of labor | Total: 40 (1.5) | Total 8 (0.3)
| | NR | Other post-op major complications, N (%) | Bladder paralysis, N (%)
| | Type of anesthesia | Major | G1: 8 (1.1)
| | NR | G1: 1 (0.2) | G2: 5 (0.6)
| | Fetal weight | G2: 4 (0.5) | G3: 10 (0.1)
| | NR | G3: NR | Total: 23 (0.9)
| | Other indications to c/d | Total: 5 (0.2)
| | Ruptured Membranes, N (%) | Minor
| | G1: NR | G1: 14 (1.9)
| | G2: 135 (15.7) Sig diff at P < 0.00 | G2: 19 (2.2)
| | G3: 889 (93.0) | G3: 23 (2.1)
| | < 12 h | Total: 56 (2.1)
| | G1: NR | Other intraoperative complications, N (%)
| | G2: 63 (7.3) | G1: 10 (1.4)
| | G3: 542 (50.6) | G2: 18 (2.1)
| | 12 to 24 h | G3: 23 (2.2)
| | G1: NR | Total: 51 (1.9)
| | G2: 26 (3.0) | Post-operative stay in hospital, days ± SD
| | G3: 261 (24.4) | G1: 7.2 ± 2.1
| | > 24 h | G2: 78 ± 3.1
| | G1: NR | G3: 7.6 ± 1.9
| | G2: 46 (5.4) | Relapocrotomy, N (%)
| | G3: 86 (8) | G1: 6 (0.8)
| | Mode of delivery, N (%) | G2: 29 (3.4)
| | G1: 100% | G3: 8 (0.8)
| | G2: 100% | Total: 43 (1.6)
| | G3: 100% | Sepsis, N (%)
| | Disproportion, N (%) | G1: NR
| | G1: 303 (42.2) P < 0.001 | G2: 5 (0.6)
| | G2: 70 (8.1) | G3: 2 (0.2)
| | G3: 200 (18.7) | Total: 7 (0.3)
| | Total 573 (21.6) | Wound infection, N (%)
| | Obstructed labor, N (%) | G1: 7 (1.0)
| | G1: NR | G2: 15 (1.7)
| | G2: NR | G3: 30 (2.8)
| | G3: 453 (42.3) | Total: 52 (2.0)
| | Total: 453 (17.1) | Pelvic infection, N (%)
| | Fetal distress, N (%) | G1: 4 (0.6)
| | G1: NR | G2: 1 (0.1)
| | G2: 260 (30.3) P < 0.001) | G3: 11 (1.0)
| | G3: 178 (16.6) | Total: 16 (1.5)
| | Total: 438 (16.5) | Endometritis, N (%)
| | Resident, N (%) | G1: 9 (1.3)
| | G1: 464 (65) | G2: 4 (0.5)
| | G2: 518 (60) | G3: 17 (1.6)
| | G3: 654 (61) | Total: 30 (1.1)
| | Obstetrician, N (%) | UTI, N (%)
| | G1: 254 (35) | G1: 18 (2.5)
| | G2: 341 (40) | G2: 29 (3.4)
| | G3: 416 (39) | G3: 33 (3.1)
| | | Total: 80 (3.0)
| | | Haematoma, N (%)
| | | G1: 19 (2.6)
| | | G2: 48 (5.6)
| | | G3: 26 (2.4)
| | | Total: 93 (3.5)
| | | Blood loss, N (%)
| | | Intraoperative
| | | G1: 34 (4.7) P < 0.001
| | | G2: 67 (7.8)
| | | G3: 93 (8.7)
| | | Total: 194 (7.3)
| | | Post-operational ≥ 1500 ml
| | | G1: 11 (1.5)
| | | G2: 25 (2.9)
| | | G3: 28 (2.6)
| | | Total: 64 (2.4)
| | | Post-operational 1000 to 1500 ml
| | | G1: 20 (2.8)
| | | G2: 32 (3.7)
| | | G3: 53 (4.9)
| | | Total: 105 (4.0)
| | | Post-operation complications N (%)
| | | Summary of major/minor
| | | G1: 189 (26.3)
| | | P < 0.001
| | | G2: 311 (36.2)
| | | G3: 446 (41.7)
| | | Total: 946 (35.7)
| | | Major
| | | G1: 19 (2.6)
| | | P < 0.001 vs emergency (G2 + G3)
| | | G2: 55 (6.4)
| | | G3: 46 (4.3)
| | | Total: 120 (4.5)
| | | Minor
| | | G1: 170 (23.7)
| | | P < 0.001 vs emergency (G2 + G3)
| | | G2: 256 (29.8)
| | | G3: 400 (37.4)
| | | Total: 826 (31.2)
Author | Objective of the study | Maternal age, mean yrs | Urinary incontinence, all women at 3 mo PP, N (%) | NR | Relevance
Wilson, Herbison, and Herbison, 1996 | To examine the relation between obstetric factors and the prevalence of urinary incontinence three months after delivery | Overall: 27.8 | G1: 400/1104 (36.2) | | Low
Setting | Definition of elective cesarean | Maternal BMI, mean | G2: 67/190 (35.3) | | Quality Rating
New Zealand, hospital-based | Unclear whether elective c/d includes labored births since referent groups include c/d in labor | Overall: 22.7 | G3: 20/87 (23.0) | | Not rated
Study design | All groups include: | Parity for all women, N (%) | G4: 22/94 (23.4)
Retrospective cohort | - Repeat; - Breech; - Multiple gestation | 1 | G5: 8/31 (25.8)
Inclusion criteria | | 180/607 (29.7) | Urinary incontinence, women with no previous incontinence, N (%)
- All women 3 months PP; - Delivered in Queen Mary Maternity Centre; - Resident in Dunedin area | | 2 | G1: 112/459 (24.4)
Exclusion criteria | | 188/498 (37.8) | G2: 27/100 (27)
- NR | | 3 | G3: 4/45 (8.9)
Groups | | 98/256 (38.3) | G4: 6150 (12.0)
G1: Spontaneous vertex | | 4 | G5: 1/13 (7.7)
G2: Forceps | | 28/80 (35.0) | OR for urinary incontinence, all women with no previous incontinence
G3: Elective c/d | | ≥ 5 | G1: 1.00
G4: C/d in 1st stage of labor | | 15/31 (48.4) | G2: 1.3 (0.8–2.3)
G5: C/d in 2nd stage of labor | | N of previous cesareans | G3: 0.3 (0.1–0.6)
N | | NR | G4: NR
G1: 1104 | | Diabetes | G5: NR
G2: 190 | | NR | Urinary incontinence, only primiparae, N (%)
G3: 87 | | Mean gestational age | G1: 115/356 (32.3)
G4: 94 | | 39.6 | G2: 48/145 (33.1)
G5: 31 | | Spontaneous onset of labor (%) | G3: 3/22 (13.6)
| | Overall: 79.3 | G4: 11/61 (18.0)
| | Type of anesthesia | G5: 4/24 (16.7)
| | NR | Urinary incontinence, only primiparae with no previous incontinence, N (%)
| | Fetal birthweight, mean gms | G1: 49/200 (24.5)
| | Overall: 3432 | OR: 1.00
| | | G2: 22/87 (25.2)
| | | OR: 1.0 (0.5–1.9)
| | | G3: 0/13 (0.0)
| | | OR: 0.2 (0.0–0.6)
| | | G4: 2/33 (6.1)
| | | OR: NR
| | | G5: 1/12 (8.3)
| | | OR: NR

Evidence Table 2. Neonatal outcomes of cesarean delivery on maternal request

Evidence Table 2. Neonatal outcomes of cesarean delivery on maternal request

Study characteristics | Objective and definitions | Labor and delivery characteristics | Short Term Neonatal Outcomes | Long Term Neonatal Outcomes | Relevance and Quality ratings
Author | Objective of the study | Maternal age median yrs | Newborn encephalopathy, N (%) | NR | Relevance
Badawi et al., 1998 | To identify intrapartum predictors of newborn encephalopathy in term infants | NR | SVD | | Moderate
Setting | Definition of elective cesarean | Maternal BMI | G1: 49 (29.9) | | Quality rating
Australia, population-based | “Planned at least 24 hrs before procedure,” probably includes labored, number NR | NR | G2: 261 (40.3) | | Fair
Study design | Indications include: | Gravidity | Unadjusted OR: 1.0 (reference category)
Case-control | - Previous cesarean delivery; - Malpresentation; - Previous difficult labor; - Intrauterine growth retardation; - Placenta previa; - Other | NR | Adjusted OR: 1.0 (reference category)
Inclusion criteria | | N of previous cesareans | Induced VD
- Term (≥ 37 ws) infants born in metro Perth 6/93 to 9/95; - Cases: moderate/severe newborn encephalopathy defined by seizures alone OR any 2 of the following lasting for > 2 hrs: abnormal consciousness, difficulty maintaining respiration (of presumed central origin), difficulty feeding (of presumed central origin), abnormal tone and reflexes within the 1st week of life; - Controls: randomly selected for population of term births in Perth, same time period | | NR | G1: 32 (19.5)
Exclusion criteria | | Diabetes | G2: 80 (20)
- Down's syndrome; - Open neural tube defects | | NR | Unadjusted OR: 1.31
Groups | | Gestational age | Adjusted OR: 1.0
G1: Infants of moderate or severe newborn encephalopathy | | NR | (0.55, 2.18)
G2: Randomly selected control | | Type of labor, N (%) | Instrumental VD
N at enrollment | | Spontaneous | G1: 42 (25.6)
G1: 164 | | G1: 90 (54.9) | G2: 62 (15.5)
G2: 400 | | G2: 220 (55.0) | Unadjusted OR: 2.23
| | Unadjusted OR: 1 | Adjusted OR: 2.34
| | Adjusted OR: 1 | (1.16, 4.70)
| | Induced | Elective c/d
| | G1: 68 (41.5) | G1: 4 (2.4)
| | G2: 122 (30.5) | G2: 58 (14.5)
| | Unadjusted OR: 1.36 | Unadjusted OR: 0.23
| | Adjusted OR: 0.97 | Adjusted OR: 0.17
| | (0.57–1.68) | (0.05, 0.56)
| | None | Emergency c/d
| | G1: 6 (3.7) | G1: 34 (20.7)
| | G2: 58 (14.5) | G2: 38 (9.5)
| | Unadjusted OR 0.25 | Unadjusted OR: 2.94
| | Adjusted OR: 0.17 | Adjusted OR: 2.17
| | (0.06–0.49) | (1.01, 4.64)
| | Type of anesthesia, N (%) | Breech maneuver
| | General anesthesia | G1: 3 (1.8)
| | G1: 18/164 (11.0) | G2: 1 (0.3)
| | G2: 11/400 (2.8) | Unadjusted OR: 9.86
| | Unadjusted OR: 4.40 | Adjusted OR: 1.54
| | Adjusted OR: 3.08 | (0.10, 25.14)
| | 1.16, 8.17)
| | Epidural
| | G1: 19/164 (11.6)
| | G2: 69/400 (17.2)
| | Unadjusted OR: 0.64
| | Adjusted OR: 0.51
| | (0.26, 1.02)
| | Fetal weight
| | NR
| | Risk factors in newborn encephalopathy, N (%)
| | Occiptoposterior presentation
| | G1: 17/164 (10.4)
| | G2: 15/400 (3.8)
| | Unadjusted OR: 2.97
| | Adjusted OR: 4.29
| | (1.74–10.54)
| | Membrane rupture to delivery interval > 12 hrs
| | G1: 32/164 (19.5)
| | G2: 53/400 (13.2)
| | Unadjusted OR: 1.59
| | Adjusted OR: 1.31
| | (0.69, 2.47)
| | Cord prolapse
| | G1: 1/164 (0.6)
| | G2: 1/400 (0.2)
| | Unadjusted OR: 2.45
| | Adjusted OR: 4.71
| | (0.21–105.02)
| | Maternal pyrexia ≥ 37.5
| | G1: 18/164 (11.0)
| | G2: 9/400 (2.2)
| | Unadjusted OR: 5.34
| | Adjusted OR: 3.82
| | (1.44, 10.12)
Author | Objective of the study | Maternal age | RDS | NR | Relevance
Dani et al., 1999 | To investigate maternal and perinatal risk factors for RDS and TT in newborn infants. | < 32 yrs | G1: 215/43,941 | | Low
Setting | Definition of elective cesarean | Overall: 40,152 | G2: 1/1621 | | Quality rating
Italy, community-based | Includes labored births. | ≥32 yrs | G3: 158/11,021 | | Not rated
Study design | Category not defined, but may include | Overall: 22,556 | G4: 360/1,351
Case-control | - Twins; - Unspecified “maternal diseases”; - Gestosis; - Placenta previa; - Placental abruption; - IUGR; - PROM; - Preconceptional Diabetes; - Isoimmunization | Maternal BMI | OR for G3 vs G1: 1.88 (1.42–2.48)
Inclusion criteria | | NR | P < 0.0001
- Infant born between 2/1/95-1/31/98 in one of 65 hospitals included (Italy) (level II or III nursery); - TT or RDS diagnosed | | Gravidity | OR for G4 vs G1: 3.46 (2.69–4.44)
Exclusion criteria | | First | P < 0.0001
- Total pneumonia or not having TT or RDS | | 28,066 | TTN
Groups | | Second | G1: 226/43,941
G1: Vaginal | | 20,335 | G2: 13/1,621
G2: Operative vaginal | | Third | G3: 157/11,021
G3: Elective c/d | | 7,230 | G4: 198/1,351
G4: Emergent c/d | | Fourth | OR for G3 vs G1: 1.86 (1.48–2.33)
N | | 2,395 | P < 0.0001
G1: 43,941 | | Fifth or more | OR for G4 vs G1: 2.86 (2.25–3.63)
G2: 1,621 | | 1,351 | P < 0.0001
G3: 11,021 | | N of previous cesareans
G4: 1,351 | | NR
| | Diabetes
| | NR
| | Gestational age, mean wks
| | < 36
| | Overall: 3,407
| | 36–42 wks
| | Overall: 59,990
| | > 42 wks
| | NR
| | Type of labor
| | NR
| | Type of anesthesia
| | NR
| | Fetal weight, mean gms
| | < 1500
| | Overall: 1,036
| | 1500–2499
| | Overall: 3,864
| | > 2500
| | Overall: 58,224
| | Maternal disease
| | Not abstractable
Author | Objective of the study | Maternal age | Mild laceration | NR | Relevance
Dessole et al., 2004 | To investigate the incidence, type, location, and risk factors of accidental fetal lacerations during cesarean delivery | NR | G1: 73/1421 | | Moderate
Setting | Definition of elective cesarean | Maternal BMI | G2: 13/1242 | | Quality rating
Italy, hospital-based | Includes labored births, number NR | NR | G3: 8/445 | | Fair
Study design | Category includes: | Gravidity | Moderate laceration
Retrospective cohort | - Repeat, macrosomia, placenta previa (32%); - Multiple gestation (51%); - Fetal anomalous presentation (17%) | NR | G1: 2/1421
Inclusion criteria | | N of previous cesareans | G2: 0/1242
- All c/d at institution from Jan 1995-Dec 2002 | | NR | G3: 0/445
Exclusion criteria | | Diabetes | Severe laceration
- None | | NR | G1: 1/1421
Groups | | Gestational age, mean yrs (range) | G2: 0/1242
G1: Emergency c/d | | Overall: 38.7, 29– 42 | G3: 0/445
G2: Scheduled c/d | | Type of labor | Total lacerations
G3: Unscheduled c/d | | NR | G1: 76/1421
N | | Type of anesthesia | OR: 1.7, compared to all fetal laceration/all cesarean deliveries
G1: 1421 | | NR | G2: 13/1242
G2: 1242 | | Fetal weight, gms (range) | OR: 0.34, compared to all fetal laceration/all cesarean deliveries
G3: 445 | | Overall: 3033.8, 825–4350 | G3: 8/445
| | | OR: 0.57, compared to all fetal laceration/all cesarean deliveries
| | | P < 0.001
Author | Objective of the study | Maternal age, mean yrs ± SD | NR | NR | Relevance
Durik, Hyde, and Clark, 2000 | To examine delivery related differences in relation to women's appraisal of their birth experience | G1: 30.12 ± 4.47 | | | Low
Setting | Definition of elective cesarean | G2: 30.54 ± 4.16 | | | Quality rating
US, hospital-based | Undefined “planned” cesareans | G3: 28.63 ± 4.12 | | | Not rated
Study design | | Education (on scale of 1, less than high school, to 8, graduate degree) ± SD
Prospective cohort | | G1: 5.8 ± 1.54
Inclusion criteria | | G2: 5.0 ± 1.53
- ≥ 18 yrs; - Between 12 and 21 wks gestation; - Living with partner although not necessarily married; - Working/having working partner; - Possessing telephone; - Able to speak English; - Literate | | G3: 5.61 ± 1.03
Exclusion criteria | | Maternal BMI
- Student; - Unemployed | | NR
Groups | | Primiparous (%)
G1: Vaginal delivery | | G1: 35
G2: Planned cesarean | | G2: 16
G3: Unplanned cesarean | | G3: 66
N at enrollment | | N of previous cesareans
G1: 477 | | NR
G2: 37 | | Diabetes
G3: 56 | | NR
Total: 96.1% | | Gestational age
% enrollment at 4 mos PP: 98.7% | | NR
| | Type of labor
| | NR
| | Type of anesthesia
| | NR
| | Fetal weight, mean gms ± SD
| | G1: 3467 ± 465
| | G2: 3437 ± 604
| | G3: 3783 ± 532
| | Self-esteem, Rosenberb's self-esteem scale ± SD
| | G1: 34.72 ± 4.86
| | G2: 34.81 ± 5.67
| | G3: 35.75 ± 3.23
| | Depression CES-D Scale ± SD
| | G1: 8.46 ± 7.51
| | G2: 1.03 ± 7.44
| | G3: 6.88 ± 4.60
| | Neuroticism measured by Eysende Personality Inventory Form A Score, ± SD
| | G1: 8.69 ± 5.40
| | G2: 9.97 ± 5.15
| | G3: 8.82 ± 5.12
Author | Objective of the study | Mean Maternal age, mean yrs | NA | NA | Relevance
Golfier et al., 2001 | To compare neonatal and maternal morbidity and mortality between planned vaginal delivery and elective cesarean delivery for term breech presentation | Overall: 29 | | | Low
Setting | Definition of elective cesarean | Maternal BMI | | | Quality rating
Western Europe, France | Probably includes labored births, number NR | NR | | | Not rated
Hospital-based | All Groups include: | Primiparous, %
Study design | - Breech | G1: 54
Retrospective cohort | | G2: 68
Inclusion criteria | | P = 0.05
- 37–42 wks; - Breech, singleton | | N of previous cesareans
Exclusion criteria | | NR
- Maternal or fetal pathology that could have affected the state of the mother or child at birth | | Diabetes
Groups | | NR
G1: Planned vaginal | | Gestational age
G2: Elective c/d | | NR
Actual mode of delivery | | Type of labor
G1: 342/414 delivered vaginally | | NR
G2: 695/702 delivered by c/d | | Anesthesia, %
N | | General
G1: 414 | | G1: 5.8
G2: 702 | | G2: 23.5
| | Regional
| | G1: 57.7
| | G2: 76.5
| | No anesthesia
| | G1: 36.5
| | G2: 0
| | Birth weight, mean gms
| | G1: 3164
| | G2: 3206
| | P > 0.05
| | Macrosomia, > 4000 gms
| | G1: NR
| | G2: NR
| | RR = 3.09 (1.46–6.5)
| | Higher in elective c/d group
| | Episiotomy, %
| | G1: 83
| | G2: NR
Author | Objective of the study | Maternal age, mean yrs ± SD | Apgar at 1 minute, N ± SD | NR | Relevance
Groutz et al., 2003 | To compare prevalence of stress urinary incontinence by mode of delivery | G1: 28 ± 4 | G1: 8.9 ± 0.45 | | Moderate
Country, Setting | Definition of elective cesarean | G2: 32.5 ± 5.3 | G2: 9.0 ± 0.14 | | Quality rating
Israel, hospital-based | No trial of labor | G3: 31.7 ± 5.2 | G3: 9.0 ± 0.06 | | Fair
Study design | Category includes: | Maternal height, mean cm ± SD | Apgar at 5 minutes, N ± SD
Prospective cohort | - Breech (70%); - Other indications not specified | G1: 164 ± 6.6 | G1: 9.97 ± 0.2
Inclusion criteria | | G2: 162 ± 5.6 | G2: 9.98 ± 0.14
- Primiparous; - Delivery at Lis Maternity Hospital | | G3: 164 ± 6.7 | G3: 10.0 ± 0
Exclusion criteria | | Maternal weight, mean kg ± SD
- Nonsingleton deliveries; - Instrumental vaginal delivery; - Those with SUI before pregnancy | | G1: 60 ± 9.0
Groups | | G2: 62.5 ± 1.6
G1: Spontaneous vaginal delivery | | G3: 63 ± 13.0
G2: Obstructed Labor cesarean delivery | | Parity, %
G3: Elective cesarean delivery | | Primiparous: 100%
N at enrollment | | N of previous cesareans
G1: 145 | | NR
G2: 100 | | Diabetes
G3: 118 | | NR
Follow-up | | Gestational age, wks ± SD
1 year | | G1: 39.7 ± 1.2
G1: 145 | | G2: 40.2 ± 1.3
G2: 100 | | G3: 38.8 ± 1.5
G3: 118 | | Type of labor
| | NR
| | Type of anesthesia Epidural
| | G1: 134/145
| | G2: NR
| | G3: NR
| | Fetal weight, mean ± SD
| | G1: 325 ± 400
| | G2: 3450 ± 420
| | G3: 3260 ± 617
| | P < 0.05
| | SUI during Pregnancy, N (%)
| | G1: 45 (31)
| | G2: 25 (25)
| | G3: 33 (28)
Author | Objective of the study | Maternal age | Persistent pulmonary hypertension, N (%) | NR | Relevance
Levine et al., 2001 | To determine whether there is an increased incidence of persistent pulmonary hypertension in neonates delivered by cesarean, with or without labor, compared with those delivered vaginally | NR | G1: 17 (0.08) | | Moderate
Setting | Definition of elective cesarean | Maternal BMI | G2: 17 (0.40) | | Quality rating
US, hospital-based | Does not include labored births | NR | P < 0.001 | | Fair
Study design | Category includes: | Gravidity | OR 4.9 (2.2–8.8)
Retrospective cohort | - Breech; - Placenta previa; - Genital herpes; - Macrosomia; - Multiple gestation; - Prior cesareans | NR | C/d vs. vaginal
Inclusion criteria | | N of previous cesareans | - G2a: 7 (0.37)
- Consecutive deliveries at the Illinois Masonic Medical Center between 1/1992 and 12/1999; - Singleton, live newborns | | NR | P < 0.01
Exclusion criteria | | Diabetes | OR 4.6 (1.3–11)
- Pre-term (≤ 35 wks); - Congenital heart disease; - Congenital diaphragmatic hernia; - Meconium aspiration | | NR | Elective vs. vaginal
Groups | | Gestational age | TTN, N (%)
G1: Vaginal deliveries | | NR | G1: 238 (1.1)
G2: All c/d | | Type of labor | G2: 151 (3.5)
- G2a: Elective c/d | | NR | P < 0.001
N at enrollment | | Type of anesthesia | OR 3.3 (2.6–3.9)
G1: 21,017 | | NR | C/d vs. vaginal
G2: 4,301 | | Fetal weight | - G2a: 59 (3.1)
G3: 1889 | | NR | P < 0.001
| | | OR: 2.8 (2.1–3.8)
| | | Elective vs. vaginal
| | | RDS, N (%)
| | | G1: 33 (0.16)
| | | G2: 20 (0.47)
| | | P < 0.001
| | | OR 3.0 (1.6–5.3)
| | | C/d vs. vaginal
| | | G3: 4 (0.2)
| | | P < 0.18
| | | OR 1.3 (0.5–3.8)
| | | Elective vs. vaginal
Author | Objective of the study | Maternal age | TTN | NR | Relevance
Morrison, Rennie, and Milton, 1995 | To establish whether the timing of delivery between 37 and 42 weeks gestation influences neonatal respiratory outcome and thus provide information which can be used to aid planning of elective delivery at term | NR | G1: 118/28578 | | Moderate
Setting | Definition of elective cesarean | Maternal BMI | G2: 53/2341 | | Quality rating
UK, hospital-based | Does not include “labored” births (defined as regular contractions and effacement plus dilation ≥ 3cm) | NR | G3: 20/2370 | | Fair
Study design | Category includes: | Gravidity/parity | RDS
Retrospective cohort | - Repeat; - Breech; - Uncomplicated previa; - Other malpresentation; - Suspected CPD; - Chorioamnionitis; - Rhesus sensitization; - IUGR; - Preeclampsia; - Fetal distress | NR | G1: 32/28578
Inclusion criteria | | N of previous cesareans | G2: 30/2341
- Required admission to NICU at gest age ≥ 37 wks with RDS or TTN (Avery et al, 1966-grunting, nasal flaring, retraction, tachypnea, poor air entry, radiographic features of either TTN or reticulogranular pattern of RDS); - Only those planned to be delivered at the teaching hosp included; - Required oxygen | | NR | G3: 9/2370
Exclusion criteria | | Diabetes | Respiratory morbidity (RDS+TTN), N (range)
- Evidence of infection including meconium aspiration or pneumonia | | NR | G1: 5.3/1000 (4.4–6.2)
Groups | | Gestational age | OR: 1.0
G1: Vaginal | | NR | G2: 35.5/1000 (28.4–43.8)
G2: Prelabor c/d | | Type of labor | OR: 6.8 (5.2–8.9)
G3: C/d in labor | | NR | G3: 12.2/1000 (8.2–17.5)
N | | Type of anesthesia | OR: 2.3 (1.6–3.5)
G1: 28578 | | NR
G2: 2341 | | Fetal weight
G3: 2370 | | NR
Author | Objective of the study | Maternal age | TTN (%) | NR | Relevance
Rubaltelli et al., 1998 | To evaluate the incidence of neonatal respiratory disorders and their risk factors | NR | G1: NR | | Low
Setting | Definition of elective cesarean | Maternal BMI | - G1a: 3.8 | | Quality rating
Italy, population-based | Undefined | NR | G2: 1.5 (P < 0.0001 compared to vaginal) | | Not rated
Study design | | Gravidity | G3: 4.2
Prospective cohort | | NR
Inclusion criteria | | N of previous cesareans
- All live infants born in selected hospitals including neonates who died in maternity wards before their transfer to a neonatal unit, in a 3 month survey of 65 hospitals in 17 regions; - Births from Feb 1 to April 30, 1995 | | NR
Exclusion criteria | | Diabetes
- None | | NR
Groups | | Gestational age
G1: Vaginal | | NR
- G1a: Forceps | | Type of labor
G2: Elective c/d | | NR
G3: Emergency c/d | | Type of anesthesia
N | | NR
G1: 12,463 | | Fetal weight
- G1a: NR | | NR
G2: 2,984
G3: 1,569
Author | Objective of the study | Maternal age, mean yrs (range) | Paresis of recurrens nerve, N (%) | NR | Relevance
Schindl et al., 2003 | To investigate birth experience and medical outcome in women with elective cesarean delivery compared with intended vaginal delivery | G1: 28 (15–43) | G1: 1/903 (0.1) | | Moderate
Setting | Definition of elective cesarean | G2a: 32 (20–44) | G2: 0 | | Quality rating
Austria, hospital-based | Probably includes labor, number NR | G2b: 30 17–44) | Respiratory adaptation problems, N (%) | | Fair
Study design | Elective c/d on demand includes: | P < 0.05 | G1: 0
Prospective cohort | - Anxiety, nulliparae (16/44); - Previous traumatic birth (20/44); - Other (coordination problems, safety considerations) (8/44) | Maternal BMI | G2: 1/147 (0.7)
Inclusion criteria | Elective c/d for medical indications includes: | NR
- Gestation week 38 | - Breech (40/103); - Twins (7/103); - Preeclampsia (6/103); - CS interval < 15 mos (19/103); - Cephalopelvic disproportion (4/103); - HIV and hepatitis C (5/103); - Neurological problems (e.g., epilepsy) (10/103); - Internal problems (e.g., heart failure) (9/103); - Others (e.g., pelvic failure) (3/103) | N of previous births mean (range)
Exclusion criteria | | G1: 0 (0–9)
- < 19 yrs; - Inability to complete questionnaire; - Unwillingness to participate; - Severe internal problems (e.g., HELLP syndrome) | | G2a: 1 (0–5)
Groups | | G2b: 0 (0–3)
G1: Intended vaginal delivery | | N of previous cesareans
G2: Elective c/d | | NR
- G2a: Elective c/d (medical reasons); - G2b: Elective c/d (“on demand”) | | Diabetes
N at enrollment | | NR
G1: 903 | | Gestational age
G2: 147 | | NR
- G2a: 103; - G2b: 44 | | Type of labor
Follow-up | | Type of anesthesia
3 days PP | | NR
NR | | Fetal weight
4 mos PP | | NR
23.9% response rate | | Other
| | NR
Author | Objective of the study | Maternal age, ≥ 35 yrs (%) | Ventilation for mainly respiratory causes (controlling for Maternal age, maternal pyrexia, gestational age 37–38 wks, birth weight < 3rd percentile) | NR | Relevance
Sutton et al., 2001 | To ascertain antenatal and intrapartum risk factors for term neonates ventilated primarily for respiratory problems. And describe the neonatal morbidity and mortality | G1: 24/99 (24.2) | OR for elective c/d vs. vaginal: 2.64 (1.42, 4.90) | | Low
Setting | Definition of elective cesarean | G2: 84/550 (15.3) | OR for emergency c/d vs. vaginal: 4.07 (2.13, 7.78) | | Quality rating
New South Wales (NSW), Australia, population-based study | Does not include labored births, but probably include mix of planned and unplanned, defined as “cesarean delivery before labor has commenced” | Maternal BMI | OR for forceps delivery vs. vaginal: 4.47 (2.11, 9.44) | | Not rated
Study design | | NR
Case-control | | Primagravida, N (%)
Inclusion criteria | | G1: 54/99 (54.6)
Cases | | G2: 230/550 (41.8)
- Singleton infants ≥ 37 gestational age born between 1/1/1996 and 12/31/1996; - Mothers resident in the area; - Require mechanical ventilation for at least 4 hrs; - Admitted to tertiary NICU in NSW with the first 96 hrs of life; - Controls; - Randomly and independently selected | | N of previous cesareans
Exclusion criteria | | NR
Cases | | Insulin dependent Diabetes, N (%)
- No major congenital anomaly; - Controls; - No mechanical ventilation; - No admission to tertiary NICU | | G1: 2/99 (2.0)
Groups | | G2: 0/550
G1: Neonates requiring mechanical ventilation | | Gestational Diabetes, N (%)
G2: Neonates not requiring mechanical ventilation | | G1: 9/99 (9.1)
N | | G2: 18/550 (3.3)
G1: 99 | | Gestational age, N of those at 37–38 wks (%)
G2: 550 | | G1: 38/99 (38.4)
| | G2: 123/550 (22.4)
| | Type of labor
| | NR
| | Type of anesthesia
| | NR
| | Birth weight, N (%)
| | < 3rd percentile
| | G1: 8/99 (8.1)
| | G2: 13/550 (24)
| | > 90th percentile
| | G1: 20/99 (20.2)
| | G2: 64/550 (11.6)
| | Maternal pyrexia, N (%)
| | G1: 4/99 (4.0)
| | G2: 4/550 (0.73)
Author | Objective of the study | Maternal age | Death before discharge (per 1,000 deliveries) | NR | Relevance
Towner et al., 1999 | To determine the incidence of rare neonatal disorders and their association with various modes of delivery, particularly vacuum extraction | NR | G1: 0.2 | | Low
Setting | Definition of elective cesarean | Maternal BMI | G2: 0.3 OR: 1.5 (0.8–2.8) | | Quality rating
US, population based | “Cesarean before labor,” probably includes a mix of planned and unplanned | NR | G3: 0.5 OR: 1.9 (0.6–5.4) | | Not rated
Study design | | Gravidity | G4: 0.6 OR: 2.6 (0.4–5.4)
Cross-deliveryal | | NR | G5: 0.8 OR: 3.7 (2.6–5.4)
Inclusion criteria | | N of previous cesareans | - G5a: NR; - G5b: NR; - G5c: NR; - G5d: 0.8, OR NR, but “no difference between infants born by cesarean delivery during labor and those born by cesarean delivery with no labor”
- All liveborn singleton neonates born to nulliparous women; - Jan 1 1992 to Dec 31 1994; - Birthweight 2500g to 4000g | | NR | Subdural or cerebral hemorrhage (per 10,000 deliveries)
Exclusion criteria | | Diabetes | G1: 2.9
- Vaginal breech | | NR | G2: 8 OR: 2.7 (1.9–3.9)
Groups | | Gestational age | G3: 9.8 OR: 3.4 (1.9–5.9)
G1: Spontaneous vaginal | | NR | G4: 21.3 OR: 7.3 (2.9–17.2)
G2: Vacuum extraction | | Type of labor | G5: 6.7 OR: 2.3 (1.7–3.1); - G5a: 7.4 OR: 2.5 (1.8–3.4); - G5b: 25.7 OR: 8.8 (3.9–19.9); - G5c: 6.8 OR: 2.3 (1.7–3.2); - G5d: 4.1 OR: 1.4 (0.8–2.6)
G3: Forceps | | NR | Intraventricular hemorrhage (per 10,000 deliveries)
G4: Forceps and vacuum | | Type of anesthesia | G1: 1.1
G5: Cesarean delivery | | NR | G2: 1.5 OR: 1.4 (0.7–3.0)
- G5a: Labored cesareans; - G5b: Labored c/d with attempt at vacuum or forceps; - G5c: Labored c/d, no attempt at vacuum or forceps; - G5d: Unlabored cesareans | | Fetal weight | G3: 2.6 OR: 2.5 (0.9–6.9)
N | | NR | G4: 3.7 OR: 3.5 (1.5–25.2)
G1: 387,799 | | | G5: 2.1 OR: 2 (1.2–3.3)
G2: 59,354 | | | - G5a: 2.5 OR: 2.3 (1.4–4.0); - G5b: 0 OR: 0 (0.0–1.1); - G5c: 2.6 OR: 2.4 (1.4–4.1); - G5d: 0.8 OR: 0.6 (0.1–2.5)
G3: 15,945 | | | Subarachnoid hemorrhage (per 10,000 deliveries)
G4: 2817 | | | G1: 1.3
G5: 117,425 | | | G2: 2.2 OR: 1.7 (0.9–3.2)
- G5a: 84,417; - G5b: 2,343; - G5c: 82,075; - G5d: 33,008 | | | G3: 3.3 OR: 2.5 (0.9–6.6)
| | | G4: 10.7 OR: 8.2 (2.1–27.4)
| | | G5: 0.9 OR: 0.7 (0.4–1.4)
| | | - G5a: 1.2 OR: 0.9 (0.4–1.9); - G5b: 4.3 OR: 3.3 (0.5–23.9); - G5c: 1.1 OR: 0.9 (0.4–1.7); - G5d: 0 OR: 0 (0.0–19.7)
| | | Facial nerve injury (per 10,000 deliveries)
| | | G1: 3.3
| | | G2: 4.6 OR: 1.7 (0.9–2.1)
| | | G3: 45.4 OR: 13.6 (10.0–18.4)
| | | G4: 28.5 OR: 8.5 (3.9–18.0)
| | | G5: 3.5 OR: 1.1 (0.7–1.5)
| | | - G5a: 3.1 OR: 0.9 (0.6–1.4); - G5b: 12.8 OR: 3.8 (1.2–12.1); - G5c: 2.8 OR: 0.8 (0.5–1.3); - G5d: 4.9 OR: 1.5 (0.8–2.6)
| | | Brachial plexus (per 10,000 deliveries)
| | | G1: 7.7
| | | G2: 17.6 OR: 2.3 (1.8–2.9)
| | | G3: 25 OR: 3.2 (2.3–4.6)
| | | G4: 46.4 OR: 6 (3.3–10.7)
| | | G5: 3 OR: 0.4 (0.3–0.5)
| | | - G5a: 1.8 OR: 0.2 (0.1–0.4); - G5b: 8.6 OR: 1.1 (0.3–4.4); - G5c: 1.6 OR: 0.2 (0.1–0.4); - G5d: 4.1 OR: 0.5 (0.3–1.0)
| | | Convulsions (per 10,000 deliveries)
| | | G1: 6.4
| | | G2: 11.7 OR: 1.8 (1.4–2.4)
| | | G3: 9.8 OR: 1.6 (0.9–2.7)
| | | G4: 24.9 OR: 3.9 (1.7–8.6)
| | | G5: 18.7 OR: 2.9 (2.4–3.6)
| | | - G5a: 21.3 OR: 3.3 (2.8–4.1); - G5b: 68.8 OR: 10.8 (6.5–17.8); - G5c: 19.9 OR: 3.1 (2.6–3.8); - G5d: 8.6 OR: 1.4 (0.9–2.1)
| | | CNS depression (per 10,000 deliveries)
| | | G1: 3.1
| | | G2: 9.2 OR: 2.9 (2.1–4.1)
| | | G3: 5.2 OR: 1.4 (0.6–2.8)
| | | G4: 21.3 OR: 6.9 (2.7–16.2)
| | | G5: 8.9 OR: 2.9 (2.2–3.7)
| | | - G5a: 9.6 OR: 3.1 (2.3–4.1); - G5b: 17.1 OR: 5.5 (1.7–15.5); - G5c: 9.4 OR: 3 (2.3–4.0); - G5d: 6.7 OR: 2.2 (1.3–3.6)
| | | Feeding difficulty (per 10,000 deliveries)
| | | G1: 68.5
| | | G2: 72.1 OR: 1.1 (1.0–1.2)
| | | G3: 74.6 OR: 1.1 (0.9–1.3)
| | | G4: 60.7 OR: 0.9 (0.5–1.5)
| | | G5: 114.7 OR: 1.7 (1.6–1.8)
| | | - G5a: 117.2 OR: 1.7 (1.6–1.8); - G5b: 94.8 OR: 1.4 (0.9–2.1); - G5c: 117.9 OR: 1.7 (1.6–1.8); - G5d: 106.3 OR: 1.6 (1.4–1.8)
| | | Mechanical ventilation (per 10,000 deliveries)
| | | G1: 25.8
| | | G2: 39.1 OR: 1.5 (1.3–1.8)
| | | G3: 45.4 OR: 1.8 (1.4–2.3)
| | | G4: 50 OR: 1.9 (1.1–3.4)
| | | G5: 96 OR: 3.7 (3.4–4.1)
| | | - G5a: 103.2 OR: 4 (3.6–4.3); - G5b: 156.1 OR: 6 (4.3–8.3); - G5c: 101.7 OR: 2.6 (2.2–3.0); - G5d: 71.3 OR: 2.8 (2.4–3.3)
Author | Objective of the study | Maternal age, mean yrs, mean yrs ± SD | Neonatal mortality | NR | Relevance
Zanardo, Simbi, Franzoi, et al., 2004 | To determine the incidence of RDS and TTN in infants electively delivered by cesarean delivery at term, to correlate their incidence with the vaginal or cesarean mode of delivery, and to examine the risk during each week of gestation between 37 + 0 and 41 + 6 weeks | G1: 30.9 ± 2.3 | G1: 0/1,284 | | Moderate
Setting | Definition of elective cesarean | G2: 29.7 ± 2.5 | G2: 0/1,284 | | Quality rating
Italy, hospital-based | Excludes labor, defined as regular contractions and effacement plus dilation≥ 3cm (Zanardo, Simbi, Franzoi et al 2004) | Maternal BMI | Apgar | | Fair
Study design | Category includes: | NR | ≤ 5 at 1 min
Case control | - Repeat (prior c/d) (51%); - Multiple gestation (twins) (8%); - Breech (25%); - Suspected CPD (5%); - Nulliparous and > 35 yrs (2%); - Fear of labor (1%); - Miscellaneous (other malpresentations, uncomplicated placenta previa, retinopathy and myopathies) (6%) | Nulliparae (%) | G1: 21/1,284
Inclusion criteria | | G1: 42 | G1: 13/1,284
- 37 0/7 to 41 6/7 weeks (LMP ± U/S); - No conditions that could increase neonatal risk | | G2: 51 | Respiratory distress syndrome
Exclusion criteria | | N of previous cesareans | G1: 29/1,284
- Acute or chronic maternal disease: hypertension, renal disease, cardiac disease, infectious disease, “etc.”; - Pregnancy induced hypertension, hydramnios, gestational Diabetes, etc.; - Fetal abnormalities, malformations, fetal distress, potential fetal asphyxia or fetal growth retardation | | NR | G2: 5/1,284
Groups | | Diabetes | OR = 2.60 (1.35–5.90)
G1: Elective cesarean delivery | | NR | P < 0.01
G2: Vaginal delivery | | Gestational age mean wks ± SD | Respiratory complications resuscitation-Phase II, N (%)
N | | G1: 38.8 ± 1.2 | G1: 71 (5.5)
G1: 1284/2361 | | G2: 38.8 ± 1.6 | G2: 44 (3.4)
G2: NR | | Type of labor | P < 0.01
Follow-up | | NR | Transient tachypnea of the newborn
NR | | Type of anesthesia | G1: 12/1,284
| | G1: Spinal for all elective | G2: 11/1,284
| | G2: NR | Pneumonia
| | Fetal weight, mean kg ± SD | G1: 1/1,284
| | G1: 3.16 ± 0.5 | G2: 1/1,284
| | G2: 3.18 ± 0.6 | Length of hospital stay, mean days ± SD
| | Fetal sex, male (%) | G1: 6 ± 0.9
| | G1: 55 | G2: 4 ± 1.1
| | G2: 53 | NICU admission
| | | G1: 17/1,284
| | | G2: 8/1,284
| | | OR = 2.14 (1.91–5.90)
| | | P < 0.01
| | | Mortality/Death
| | | G1: 0
| | | G2: 0
Author | Objective of the study | Maternal age, mean yrs ± SD | Apgar | NR | Relevance
Zanardo, Simbi, Vedovato et al., 2004 | To examine the association between timing of delivery between 37 and 42 weeks and neonatal resuscitation risk in elective c/d | G1: 30.9 ± 2.3 | ≤ 5 at 1 min | | Moderate
Setting | Definition of elective cesarean | G2: 29.7 ± 2.5 | G1: 21/1,284 | | Quality rating
Italy, hospital | Excludes labor, defined as regular contractions and effacement plus dilation ≥ 3cm | Maternal BMI | G2: 13/1,284 | | Fair
Study design | Cases includes: | NR | ≤ at 5 min
Case-control | - Repeat c/d; - Breech; - Twin; - Cephalopelvic disproportion; - Fear of labor; - Uncomplicated placenta previa; - Retinopathy; - Myopathies | Nulliparae (%) | G1: 4/1,284
Inclusion criteria | | G1: 42 | G2: 3/1,284
- Term pregnancies (37 to 42 wks), estimated by last menstrual period or sonogram, retaining women undergoing elective cesareans before labor for the elective group (i.e., when c/d was performed on clear maternal request) and matching vaginal deliveries | | G2: 51 | PPV resuscitation
Exclusion criteria | | N of previous cesareans | G1: 44/1,284
- Excludes women with prenatally identified factors: not complicated by conditions that might increase risk to the neonates, including acute and chronic maternal illnesses, disorders of preg, fetal abnormalities, fetal distress, or potential fetal asphysia insult, and fetal growth retardation | | NR | G2: 18/1,284
Groups | | Diabetes | OR = 2.05 (1.25–5.67)
G1: Elective cesarean | | NR | P < 0.01
G2: Vaginal delivery | | Gestational age, mean wks ± SD | Respiratory distress syndrome
N | | G1: 38.8 ± 1.2 | G1: 29/1,284
G1: 1,284 | | G2: 38.8 ± 1.6 | G2: 5/1,284
G2: 1,284 | | Type of labor | OR = 2.60 (1.35–5.90)
| | NR | P < 0.01
| | Type of anesthesia | Transient tachypnea of the newborn
| | G1: Spinal for all elective | G1: 12/1,284
| | G2: NR | G2: 11/1,284
| | Fetal weight, mean kg ± SD | Pneumonia
| | G1: 3.16 ± 0.5 | G1: 1/1,284
| | G2: 3.18 ± 0.6 | G2: 1/1,284
| | Fetal sex, male (%) | Length of hospital stay, mean days ± SD
| | G1: 55 | G1: 6 ± 0.9
| | G2: 53 | G2: 4 ± 1.1
| | | NICU admission
| | | G1: 17/1,284
| | | G2: 8/1,284
| | | OR = 2.14 (1.91–5.90)
| | | P < 0.01