# Appendix B: Sample Review Forms/Quality Rating Forms

Systematic Review of Cesarean Delivery on Maternal Request

Data Abstraction Form

Reference ID Number: ___ ___ ___ ___ Reviewer's Initials: ___ ___ Date of Review: ___/___/2005

Directions : Please complete ALL questions below.

Note : These questions are for whether an article will be included in the review. There is an opportunity at the bottom of the page to request an article for background or the decision analysis even if it doesn't meet criteria for the review.

1. Published between 1990 and 2005 | | Yes | No | Cannot Determine
2. Published in English | | Yes | No | Cannot Determine
3. Study located in any of the following: United States, Canada, United Kingdom, Western Europe, Japan, Australia, New Zealand | | Yes | No | Cannot Determine
| | If No, check one of the following: | □ Brazil | □ S. Africa
| | | □ Israel | □ Other: ______________
4. Includes women of reproductive age or older with singleton birth(s) | | Yes | No | Cannot Determine
5. Addresses one or more of the following (check all that apply) | | Yes | No | Cannot Determine
□ Trend & incidence of cesarean delivery (KQ1)
□ Maternal & infant short- and long-term outcomes of elective cesarean. NOTE: A comparison between elective cesarean and attempted vaginal delivery is required in order to answer this key question (KQ2)
□ Factors affect magnitude of the benefits & harms of elective cesarean (KQ3)
□ Future research directions (KQ4)
6. Study design is one of the following (check one box if “Yes”): | | Yes | No | Cannot Determine
□ RCT | □ Observational Study
7. Sample size is appropriate (Please check correct sample size if Yes) | | Yes | No | Cannot Determine
□ If RCT, N≥50 (NOTE: This refers to the # randomized) | | □ If No, check if maternal psychosocial outcomes were measured in the study
□ If Observational, N≥100

Please check one of the options below based on your answers to Q1–Q7 above

PULL Article | □ Abstract meets ALL inclusion criteria above Abstract meets some inclusion criteria above; we cannot determine some criteria
| Abstract does NOT meet one or more of the inclusion criteria above but may be important for the background, the discussion, hand searching the references, or the decision analysis
DO NOT Pull Article | Abstract does NOT meet one or more of the criteria above and we do not need it for any other purpose

Reference ID Number: ___ ___ ___ ___ Reviewer's Initials: ___ ___ Date of Review: ___/___/2005

Directions : This form contains questions pertaining to whether an article will be included in the review or excluded. Please complete ALL of the questions unless otherwise directed. If there is an asterisk next to an answer, please complete the necessary information in the left column.

Inclusion Criteria | | | Does article meet criteria?
1. Is the article published between January 1990 and May 2005? | | | Yes | No
2. Is the article published in English? | | | Yes | No
3. Is the article original research? e.g., RCTs, cohort studies, case control studies, case series >100 | | | Yes (Go to Q5) | No (Go to Q4)
4. Is the article a meta-analysis or systematic review? | | | Yes* | No
*As directed, please separate these from the rest of the articles when returning | | | (Complete Q7 & Final Status)
Q7 should be completed for all articles; Q5–6, Q8–10 should be completed for original research ONLY
5. Is the study located in any of the following: United States, Canada, United Kingdom, Western Europe, Japan, Australia, New Zealand | | | Yes | No*
*If NO, please check one of the following: | □ Brazil | □ Other: ___________________
| □ Israel
| □ S. Africa
6. Does the study include women of reproductive age or older with term, singleton births AND/OR neonates/infants/newborns/etc? | | | Yes | No
7. Does the study address one or more of the following key questions?
*If YES, please check all that apply: | | | Yes* | No
□ Trend & incidence of cesarean delivery (KQ1)
□ Maternal & infant short- and long-term outcomes of elective cesarean (KQ2); - NOTE: A comparison between elective cesarean and attempted vaginal delivery is required in order to answer this key question; □ Factors that affect magnitude of the benefits & harms of elective cesarean (KQ3); - NOTE : This question refers to modifiers of outcomes of cesarean (KQ2), NOT the incidence/risk of cesarean (KQ1); - NOTE : A comparison between elective cesarean and attempted vaginal delivery is NOT necessary to answer this question. However, if the article addresses only vaginal delivery, it is not eligible for this question
□ Future research directions (KQ4)
8. Is the study an RCT or observational study? | | | Yes* | No
*If YES, please check one of the following: □ RCT □ Observational Study | | | | (STOP! Go to Final Status)
9. Is the sample size appropriate?
*If YES, please check which scenario applies: | | | Yes* | No**
□ If RCT, N≥50 (NOTE: This refers to the # randomized)
□ If Observational, N≥100
**□ If NO, check here if psychosocial outcomes were measured
10. What is the total sample size of this study? | | | N= _______

[underlined: FINAL STATUS OF FULL-TEXT ARTICLE]

□ Check here if “YES” is circled for all questions above, except Q4

STOP! Article will be included in the review & data will be abstracted.

□ Check here if any “NO” is circled above

(Check one or more of the boxes below for final action)

□ Hand search refs

□ Use for background

□ Use for discussion

□ Use for decision analysis

□ Exclude from everything

[underlined: SECTION 1: REVIEWER & ARTICLE IDENTIFIERS]

1. Abstractor's Initials: ___ ___ | 2. Date of Abstraction: ___ / ___ / ___
2. Article Number: ___ ___ ___ ___ | 4. Date of Publication: ___ / ___ / ___

[underlined: SECTION 2: FUNDING & SETTINGS]

5. How was the study funded? ( check all that apply )

□ Industry | □ Private Foundation
□ Government | □ Hospital / Managed Care Organization
□ Professional Society | □ Consumer / Patient Foundation
□ Not reported or unclear | □ Other (please specify): ____________________________

6. In what countries does the study take place? ( check all that apply )

□ United States

□ Canada

□ United Kingdom (includes England, Scotland, Wales, 1/6 of Ireland)

□ Japan

□ Brazil

□ Israel

□ Australia

□ New Zealand

□ Western Europe (please check all that apply below)

□ Andorra | □ Austria | □ Azores | □ Belgium | □ Denmark | □ Faroe Island
□ Finland | □ France | □ Germany | □ Gibraltar | □ Greece | □ Greenland
□ Iceland | □ Ireland | □ Italy | □ Liechtenstein | □ Luxembourg | □ Madeira
□ Malta | □ Monaco | □ Netherlands | □ Norway | □ Portugal | □ San Marino
□ Spain | □ Sweden | □ Switzerland

*If countries are other than above, please explain here: ___________________________________________________

_______________________________________________________________________________________________

_______________________________________________________________________________________________

7. What is the source of the populations? ( check all that apply and describe below )

□ Hospital/Labor & Delivery Unit/Maternity Unit/Outpatient Clinic/NICU (specific)

□ Community based (clustering of above, not quite as specific)

□ Population based (entire city/country/etc such as from an administrative database)

Description of population: ________________________________________________________________________________________________________________________

8. What are the sources of data? ( check all that apply)

□ Survey ________________________________

□ Questionnaire(s) in person ________________________________

□ Questionnaire(s) via mail, email, or internet ________________________________

□ Administrative database (*describe→) ________________________________

□ Physical Exam ________________________________

□ Interview in person ________________________________

□ Interview via telephone ________________________________

□ Medical records query ________________________________

9. Data was collected between ___/___/___ and ___/___/___ (In other words, when was the study?)

[underlined: SECTION 3: INCLUSION & EXCLUSION CRITERIA]

10. Please list the criteria for inclusion and/or exclusion ( however presented in the article ) below:

Inclusion | Exclusion
__________________________________ | ____________________________________
__________________________________ | ____________________________________
__________________________________ | ____________________________________
__________________________________ | ____________________________________
__________________________________ | ____________________________________
__________________________________ | ____________________________________

[underlined: SECTION 4: STUDY DESIGN]

11. Is the study a randomized controlled trial of unlabored/planned/elective cesarean delivery compared to an attempted vaginal delivery? ( NOTE: attempted vaginal delivery could result in a labored cesarean )

□ Yes (Complete section 4A)

□ No (Complete section 4B)

[underlined: SECTION 4A: RANDOMIZED CONTROLLED TRIAL (RCT)]

12. Briefly describe the randomization method: _______________________________________________________________________________________________________________________________

13. How many randomized groups are in this study? ____________

14. Was the randomization method sound?

□ Yes | □ No

Notes: ________________________________________________________________________

_______________________________________

15. Describe the randomized groups ( Note: Continue to keep this order throughout the rest of the form ):

a ___________________________________________________________________________
b ___________________________________________________________________________
c ___________________________________________________________________________
d ___________________________________________________________________________
e ___________________________________________________________________________
f ___________________________________________________________________________
g ___________________________________________________________________________

16. Were statistical tests of the groups reported?

□ Yes | □ No

17. Was true randomization achieved?

□ Yes | □ No

Describe the evidence for or against balance among the groups: ________________________________________________________________________________________________________________________________________________________________________________________________________________

18. Were there any post-randomization exclusions?

□ Yes | □ No

Describe the post-randomization exclusions: __________________________________________________________________________________________________________________________________________________

19. Give the number of women randomized to each group at the beginning of the study:

a ________
b ________
c ________
d ________
e ________
f ________
g ________

TOTAL # randomized in the study = _______

20. Describe WHEN randomization took place ( i.e., in relationship to labor & delivery )

_______________________________________________________________________________________________________________________________________________________________________________

21. Was any form of masking attempted & carried out during the study? ( NOTE: This could occur, for example, if the staff person interviewing the woman 6 months after delivery does not know what the woman had been randomized to )

□ Yes→ (Describe): __________________________________________________

□ No ____________________________________________________________

22. Was there any cross-over in this study?

□ Yes (Describe): __________________________________________________

□ No ____________________________________________________________

23. Was an intent-to-treat analysis conducted?

□ Yes | □ No

24. Which analysis is presented?

□ As randomized (intent-to-treat)

□ As happened (removing post-randomization exclusions and crossovers)

□ Both *Abstract both sets of data

[underlined: SECTION 4B: OBSERVATIONAL STUDY (OBS)]

25. What is the design of this observational study? ( Check one )

□ Cohort

□ Case-control

□ Large case-series

□ Cross-sectional (e.g., survey, admin dataset, medical record query)

NOTE : If the study was an RCT that randomized women to groups other than unlabored cesareans vs attempted vaginal birth BUT the data is presented using these groups, we will consider the study an observational cohort study. If applicable, please describe:

________________________________________________________________________________________________________________________________________________________________

26. Is the data collected prospectively or retrospectively?

□ Prospectively | □ Retrospectively

27. DESCRIBE AND DEFINE the mode of delivery groups being compared in this study:

NOTE : If the study ONLY addresses KQ3, we are not comparing mode of delivery groups. You will either have one group of elective cesarean or one group of cesarean that includes both elective (unlabored) and non-elective (labored, emergency) cesareans. If the study includes both of these cesarean groups, include both groups below.

a. ____________________________________________________________________________

b. ____________________________________________________________________________

c. ____________________________________________________________________________

d. ____________________________________________________________________________

e. ____________________________________________________________________________

f. _____________________________________________________________________________

g. _____________________________________________________________________________

h. _____________________________________________________________________________

[underlined: SECTION 5: FOLLOW UP OF PARTICIPANTS]

28. In the table below, please document the timepoints of follow up in the study in relationship to either randomization or the beginning of the study. Please also document the number of participants, as a fraction, who were available for follow up at that timepoint within each group. The denominator should be the number randomized, with necessary adjustments, or the number of participants at the beginning of the study, who are eligible to provide data at that timepoint. ( Note: Use the largest numerator that was available during each timepoint, even if not all the participants supplied data for every outcome ).

Timepoint of Data Collection↓ | Group A _________ | Group B _________ | Group C _________ | Group D _________ | Group E _________
a. Number enrolled (X/X should =100%) | / | / | / | / | /
b. Number randomized (RCT) or selected (OBS) at start of study | / | / | / | / | /
c. | / | / | / | / | /
d. | / | / | / | / | /
e. | / | / | / | / | /
f. | / | / | / | / | /
g. | / | / | / | / | /
h. | / | / | / | / | /

29. Was any loss-to-followup differential across study groups?

□ Yes | □ No

Describe: _______________________________________________________________________________________________________________________________________________________________________________________________________________________________________________

[underlined: SECTION 6: CHARACTERISTICS OF PARTICIPANTS]

Characteristic | How defined/measured | Data (Raw data, Point estimates)
| | [underlined: Study Groups]
| | A _______ _______ | B _______ _______ | C _______ _______ | D _______ _______ | Total
30. Maternal Age
31. Maternal Race
32. Maternal BMI
33. Education
34. Marital Status
35. Income/SES
36. Gravidity/Parity
37. Previous C/S
38. Medical Conditions
39. Previous Pelvic or Abdominal Surgery
40. Other characteristic of participant
41. Other characteristic of participant
42. Other characteristic of participant

43. Is this population of women homogenous with regards to one of the participant characteristics (i.e., all nulliparous, all women with previous cesarean deliveries)?

□ Yes* → Describe:____________________________________________________________

□ No

*NOTE: This study may be included for Key Question 2B---outcomes of elective cesarean vs trial of labor in a subpopulation of women---if you answered yes to the question above.

[underlined: SECTION 7: CHARACTERISTICS OF THE PREGNANCY, LABOR & DELIVERY]

44. How are labor and/or the stages of labor defined in this study?________________________________________________________________________________________________________________________________________________________________________________________________________________________________________________

Characteristic | How defined/measured | Data (Raw data, Point estimates)
| | [underlined: Study Groups]
| | A _______ _______ | B _______ _______ | C _______ _______ | D _______ _______ | Total
45. Prenatal care
46. Gestational Age/Pregnancy Dating
47. Pregnancy related conditions (e.g., Preeclampsia)
48. Abnormal placentation
49. Presentation
50. Other contraindications to labor
51. Augmentation of labor (e.g., induction)
52. Rupture of membranes
53. Fetal heart rate (i.e., abnormal heart rate)
54. Meconium
55. Fetal weight
56. Fetal sex
57. Anesthesia
58. Episiotomy
59. Timing of delivery/Length of labor
60. Mode of delivery
61. Complications during delivery (e.g., cord prolapse, chorioamnio.)
62. Characteristic of delivery technique
63. Characteristic of repair/suture technique/materials
64. Other characteristic of labor/delivery
65. Other characteristic of labor/delivery
66. Other characteristic of labor/delivery

67. Is this population of infants homogeneous with regards to one of the characteristics (i.e., all breech)?

□ Yes* → Describe: _________________________________________________________________

□ No

*NOTE: This study may be included for Key Question 2B---outcomes of elective cesarean vs trial of labor in a subpopulation of infants---if you answered yes to #68.

[underlined: SECTION 8: CHARACTERISTICS OF THE SETTING]

Characteristic | How defined/measured | Data (Raw data, Point estimates)
| | [underlined: Study Groups]
| | A _______ _______ | B _______ _______ | C _______ _______ | D _______ _______ | Total
68. Time of day of delivery
69. Physician Experience
70. Standard of care/delivery volume*

*If a study is comparing two hospitals or delivery units, this question will be especially pertinent

[underlined: SECTION 9: OUTCOMES OF ELECTIVE C/S VS. TRIAL OF LABOR]

If the study reports outcome data comparing an elective cesarean/unlabored cesarean group to one or more groups that began with a trial of labor, report the outcomes below. There are four sections: maternal short-term outcomes, maternal long-term outcomes, neonatal short-term outcomes, and neonatal long-term outcomes. Short term is defined as before one year post-delivery. Long term outcomes are those occurring at one year past delivery and beyond.

THE STUDY MUST REPORT DATA FOR AN ELECTIVE, UNLABORED CESAREAN GROUP AND AT LEAST ONE TRIAL OF LABOR GROUP, WHICH COULD INCLUDE LABORED C/S, TO BE INCLUDED IN THIS SECTION!

An explanation of the columns in the tables:

Code: Outcomes will be grouped with like outcomes, using a numerical code. The codes for each outcome can be found before each of the tables in the four sections of outcomes.

Outcome: What is the specific outcome? How is it labeled in the study results?

Definition: How does the study define the outcome?

Measured How: How did the study measure this particular outcome and who measured it?

Measured When: At what timepoint was this outcome measured in the study?

Data: Enter the raw data, with both numerator and denominators, for each mode of delivery group. Also enter any of the statistical findings here. If there are no numbers, enter p-values, exact quotes, etc that explain the findings.

NOTE: Each row in the table corresponds to an outcome at one timepoint. If the outcome is assessed at more than one timepoint, the data should be reported on as many rows as there are timepoints.

71. MATERNAL SHORT-TERM OUTCOMES (A)

A1=Mortality

A2=Intraoperative/Intrapartum Complications (e.g., injury to bladder/ureter/bowel, extension of incisions, perineal lacerations, haematoma)

A3=Anesthesia Issues (e.g., complications from)

A4=Hemorrhage (e.g., require blood transfusion, require D&C, blood loss, require gravid hysterectomy)

A5=Postoperative or postpartum pain

A6=Wound Complications (e.g., infection, breakdown, dehiscence)

A7=Infection (NOT of the incision) (e.g., pneumonia, UTI, mastitis, other infection)

A8=Thromboembolic Complications (e.g., deep-vein thrombosis (DVT), pulmonary embolism)

A9=Other Complications (e.g., acute respiratory distress syndrome, hypertension, ileus, bowl obstruction)

A10=Breastfeeding (e.g., ability/desire to breastfeed)

A11=Psychological (e.g., general feeling regarding birth experience, early post-partum depression, transition issues)

A12=Maternal Recovery (e.g., length of stay in hospital, need for ICU admit, hospital readmit)

Extra table space for additional outcomes or extra study groups can be found on the back of this page.

Outcome Code | Specific Name of Outcome as described by study | Definition of Outcome (Include all details presented by study) | How is the outcome measured & by whom? | When is this outcome measured? | [underlined: Outcome Data by Study Groups]
| | | | | A _______ _______ | B _______ _______ | C _______ _______ | D _______ _______ | Total
[underlined: (Example from reference #31)] | | | | | [underlined: Unlabored C/S] | [underlined: SVD *Referent] | [underlined: Assisted VD *Referent] | [underlined: Labored C/S *Referent]
A6 | “Wound infection” (see table 3) | Infected abdominal or episiotomy wound | Nova Scotia Atlee Perinatal Database | Not reported | 11 / 721 (1.5%) | 55 / 12,607 (0.4%) RR=3.5 (1.8, 6.7)* *P<0.001 | 70 / 3,613 (2.0%) RR=0.8 (0.4, 1.5) | 32 / 1,480 (2.2%) RR=0.7 (0.4, 1.4) | Not applicable

[underlined: 71. MATERNAL SHORT-TERM OUTCOMES (A)]

A1=Mortality

A2=Intraoperative/Intrapartum Complications (e.g., injury to bladder/ureter/bowel, extension of incisions, perineal lacerations, haematoma)

A3=Anesthesia Issues (e.g., complications from)

A4=Hemorrhage (e.g., require blood transfusion, require D&C, blood loss, require gravid hysterectomy)

A5=Postoperative or postpartum pain

A6=Wound Complications (e.g., infection, breakdown, dehiscence)

A7=Infection (NOT of the incision) (e.g., pneumonia, UTI, mastitis, other infection)

A8=Thromboembolic Complications (e.g., deep-vein thrombosis (DVT), pulmonary embolism)

A9=Other Complications (e.g., acute respiratory distress syndrome, hypertension, ileus, bowl obstruction)

A10=Breastfeeding (e.g., ability/desire to breastfeed)

A11=Psychological (e.g., general feeling regarding birth experience, early post-partum depression, transition issues)

A12=Maternal Recovery (e.g., length of stay in hospital, need for ICU admit, hospital readmit)

EXTRA SPACE!

Outcome Code | Specific Name of Outcome as described by study | Definition of Outcome (Include all details presented by study) | How is the outcome measured & by whom? | When is this outcome measured? | [underlined: Outcome Data by Study Groups]
| | | | | A _______ _______ | B _______ _______ | C _______ _______ | D _______ _______ | Total

[underlined: 72. MATERNAL LONG-TERM OUTCOMES (B)]

B1=Urinary Function (e.g., urinary incontinence, vesicovaginal fistulas)

B2=Pelvic Organ Prolapse

B3=Anorectal Function (e.g., fecal/flatus incontinence, rectovaginal fistulas)

B4=Sexual Function/Dyspareunia

B5=Subsequent Uterine Rupture

B6=Subsequent Placental Implantation Issues (e.g., previa, accrete)

B7=Future Obstetric or Gynecological Issues (e.g., infertility, endometriosis, pelvic pain, subsequent ectopic pregnancy, subsequent stillbirth)

B8=Psychological (e.g., post-partum depression, anxiety)

Extra table space for additional outcomes or extra study groups can be found on the back of this page.

Outcome Code | Specific Name of Outcome as described by study | Definition of Outcome (Include all details presented by study) | How is the outcome measured & by whom? | When is this outcome measured? | [underlined: Outcome Data by Study Groups]
| | | | | A _______ _______ | B _______ _______ | C _______ _______ | D _______ _______ | Total

[underlined: 72. MATERNAL LONG-TERM OUTCOMES (B)]

B1=Urinary Function (e.g., urinary incontinence, vesicovaginal fistulas)

B2=Pelvic Organ Prolapse

B3=Anorectal Function (e.g., fecal/flatus incontinence, rectovaginal fistulas)

B4=Sexual Function/Dyspareunia

B5=Subsequent Uterine Rupture

B6=Subsequent Placental Implantation Issues (e.g., previa, accrete)

B7=Future Obstetric or Gynecological Issues (e.g., infertility, endometriosis, pelvic pain, subsequent ectopic pregnancy, subsequent stillbirth)

B8=Psychological (e.g., post-partum depression, anxiety)

EXTRA SPACE!

Outcome Code | Specific Name of Outcome as described by study | Definition of Outcome (Include all details presented by study) | How is the outcome measured & by whom? | When is this outcome measured? | [underlined: Outcome Data by Study Groups]
| | | | | A _______ _______ | B _______ _______ | C _______ _______ | D _______ _______ | Total

[underlined: 73. NEONATAL SHORT-TERM OUTCOMES (C)]

C1=Mortality (e.g., neonatal or fetal)

C2=APGAR Scores

C3=Birth Injury (e.g., lacerations, fractures, brachial plexus injury, spinal cord injury, intraventricular hemorrhage, subdural/cerebral hemorrhage, subarachnoid hemmorhage)

C4=Respiratory Complications (e.g., Transient tachypnea, respiratory distress syndrome, persistent pulmonary hypertension, requires mechanical ventilation/intubation; NOTE: iatrogenic prematurity often results in respiratory complications and should be included in this category)

C5=Neurologic Complications (e.g., Encephalopathy/asphyxia, seizures, cerebral accidents, stroke)

C6=Infections (e.g., Group B streptococcus infection, sepsis, pneumonia, necrotizing enterocolitis)

C7=Other Complications (e.g., gastrointestinal, metabolic)

C8=Bonding/Transition (e.g., breastfeeding, bonding)

C9=Recovery (e.g., unplanned NICU stay, special care nursery, length of stay)

Extra table space for additional outcomes or extra study groups can be found on the back of this page.

Outcome Code | Specific Name of Outcome as described by study | Definition of Outcome (Include all details presented by study) | How is the outcome measured & by whom? | When is this outcome measured? | [underlined: Outcome Data by Study Groups]
| | | | | A _______ _______ | B _______ _______ | C _______ _______ | D _______ _______ | Total

[underlined: 73. NEONATAL SHORT-TERM OUTCOMES (C)]

C1=Mortality (e.g., neonatal or fetal)

C2=APGAR Scores

C3=Birth Injury (e.g., lacerations, fractures, brachial plexus injury, spinal cord injury, intraventricular hemorrhage, subdural/cerebral hemorrhage, subarachnoid hemmorhage)

C4=Respiratory Complications (e.g., Transient tachypnea, respiratory distress syndrome, persistent pulmonary hypertension, requires mechanical ventilation/intubation; NOTE: iatrogenic prematurity often results in respiratory complications and should be included in this category)

C5=Neurologic Complications (e.g., Encephalopathy/asphyxia, seizures, cerebral accidents, stroke)

C6=Infections (e.g., Group B streptococcus infection, sepsis, pneumonia, necrotizing enterocolitis)

C7=Other Complications (e.g., gastrointestinal, metabolic)

C8=Bonding/Transition (e.g., breastfeeding, bonding)

C9=Recovery (e.g., unplanned NICU stay, special care nursery, length of stay)

EXTRA SPACE!

Outcome Code | Specific Name of Outcome as described by study | Definition of Outcome (Include all details presented by study) | How is the outcome measured & by whom? | When is this outcome measured? | [underlined: Outcome Data by Study Groups]
| | | | | A _______ _______ | B _______ _______ | C _______ _______ | D _______ _______ | Total

[underlined: 74. NEONATAL LONG-TERM OUTCOMES (D)]

D1=Bonding & Behavioral Issues (e.g., transitional issues)

D2=Long-term physical development

Extra table space for additional outcomes or extra study groups can be found on the back of this page.

Outcome Code | Specific Name of Outcome as described by study | Definition of Outcome (Include all details presented by study) | How is the outcome measured & by whom? | When is this outcome measured? | [underlined: Outcome Data by Study Groups]
| | | | | A _______ _______ | B _______ _______ | C _______ _______ | D _______ _______ | Total

[underlined: 74. NEONATAL LONG-TERM OUTCOMES (D)]

D1=Bonding & Behavioral Issues (e.g., transitional issues)

D2=Long-term physical development

EXTRA SPACE!

Outcome Code | Specific Name of Outcome as described by study | Definition of Outcome (Include all details presented by study) | How is the outcome measured & by whom? | When is this outcome measured? | [underlined: Outcome Data by Study Groups]
| | | | | A _______ _______ | B _______ _______ | C _______ _______ | D _______ _______ | Total

[underlined: 75. SECTION 10: MODIFIERS OF OUTCOMES OF ELECTIVE C/S]

NOTE: The study must meet two criteria to be included in this section

1 The modifier under study needs to have a comparison group. In other words, the outcome should be studied in more than one strata of the modifier (i.e., with and without the modifier, several strata of the modifier compared to a referent strata of the modifier).
2 We only need to see the outcome by strata of modifier within the elective c/s group. If there is only a cesarean group, and we know that it is a mix of elective/unlabored cesareans in it, we will collect that data. If the only cesarean group is only comprised of labored cesareans, we will not include the study in this section.

The outcome codes may be found above in section 9. They include A1 through A12, B1 through B8, C1 through C9, and D1 through D2.

Extra table space for additional outcomes or extra study groups can be found on the back of this page.

Modifier | How is the modifier defined? What are the strata? | How is the modifier measured and by whom? | Outcome code from section 9 | Specific Outcome & When Measured | [underlined: Outcome data by cesarean study groups]
| | | | | Group A ____________ ____________ | Group B ____________ ____________
[underlined: (Example from Reference #72)] | | | | | [underlined: Group=Cesarean]
Birth Weight (g) from table 4 | <3000g 3000g–3999g ≥4000g | Not explained but probably understood to be weighed by nurse in delivery room | A4 | Intraoperative blood loss ≥1000mL during the C/S | 247/923 (26.8%) 505/923 (54.7%) 171/923 (18.5%) | Adj OR=1.5 (1.2–4.6) Adj OR=1.0 (ref) Adj OR=2.7 (2.0–8.1)

[underlined: 75. SECTION 10: MODIFIERS OF OUTCOMES OF ELECTIVE C/S]

NOTE: The study must meet two criteria to be included in this section

1 The modifier under study needs to have a comparison group. In other words, the outcome should be studied in more than one strata of the modifier (i.e., with and without the modifier, several strata of the modifier compared to a referent strata of the modifier).
2 We only need to see the outcome by strata of modifier within the elective c/s group. If there is only a cesarean group, and we know that it is a mix of elective/unlabored cesareans in it, we will collect that data. If the only cesarean group is only comprised of labored cesareans, we will not include the study in this section.

The outcome codes may be found above in section 9. They include A1 through A12, B1 through B8, C1 through C9, and D1 through D2.

EXTRA SPACE

Modifier | How is the modifier defined? What are the strata? | How is the modifier measured and by whom? | Outcome code from section 9 | Specific Outcome & When Measured | [underlined: Outcome data by cesarean study groups]
| | | | | Group A ____________ ____________ | Group B ____________ ____________

[underlined: 76. SECTION 11: FUTURE RESEARCH]

The article may speak to the need for future research (KQ4). If you want to highlight direct quotes or ideas from the paper, please give the page number, other location information, and the quote or idea below.

Page Number | Other location information (e.g., column, paragraph number.) | Quote, idea, etc.
| NOTE: Feel free to highlight or underline on the actual article to aid in location | NOTE: If you've given good location information, don't write the entire quote out here.

[underlined: SECTION 12: PRELIMINARY ASSESSMENT OF QUALITY]

77. How would you rate the study's ability to operationalize their definitions of characteristics, outcomes, and modifiers? ( Circle one )

GOOD FAIR POOR

78. Overall, how would you rate this article? ( Circle one )

NOTE: Keep in mind their randomization techniques, loss-to-followup problems, their ability to define everything clearly, possible selection bias, and analysis methods.

GOOD FAIR POOR

Reference ID: _______________.

Check one:

Maternal Outcomes | □ Short-term
| □ Long-term

Neonatal Outcomes | □ Short-term
| □ Long-term

Outcome Code (see long form) | Specific Name of Outcome as described by study | Definition of Outcome (Include all details presented by study) | How is the outcome measured & by whom? | When is this outcome measured? | [underlined: Outcome Data by Study Groups]
| | | | | A _______ _______ | B _______ _______ | C _______ _______ | D _______ _______ | Total

Systematic Review of Cesarean Delivery on Maternal Request

Full Text Review Form: Previa Meta-Analysis Update

Reference ID Number: ___ ___ ___ ___ Reviewer's Initials: ___ ___ Date of Review: ___/___/2005

NOTE: This form is to evaluate the inclusion of article pertaining to placenta previa according to the original meta-analysis (Ref #1212, Faiz AS & Ananth CV, “Etiology and risk factors for placenta previa: an overview and meta-analysis of observational studies.”). Follow the directions after each answer you circle.

1. Is the study published between March 2000 and May 2005? | Yes | No
| Continue | STOP-Exclude
2. Is the study published in English? | Yes | No
| Continue | STOP-Exclude
3. Is the study an observational study of placenta previa? | Yes | No
NOTE: Case reports on placenta previa and studies on placental abruption will NOT be included | Continue | STOP-Exclude
4. Is placenta previa diagnosed in early pregnancy (first or second trimester)? | Yes | No
| STOP-Exclude | Continue
5. Are data about cesarean delivery as a risk factor for placenta previa presented? | Yes | No
| Continue | STOP-Exclude

Please check one option below based on your answers to Q1–Q5.

INCLUDE□ “Yes” is circled for all questions above

EXCLUDE□ Any “No” is circled above

Systematic Review of Cesarean Delivery on Maternal Request

Abstract Review Form: Previa Meta-Analysis Update

Reference ID Number: ___ ___ ___ ___ Reviewer's Initials: ___ ___ Date of Review: ___/___/2005

NOTE: This form is to evaluate the inclusion of article pertaining to placenta previa according to the original meta-analysis (Ref #1212, Faiz AS & Ananth CV, “Etiology and risk factors for placenta previa: an overview and meta-analysis of observational studies.”). Follow the directions after each answer you circle.

1. Is the study published between March 2000 and May 2005? | Yes | No | Cannot Determine
| Continue | STOP-Exclude | Continue
2. Is the study published in English? | Yes | No | Cannot Determine
| Continue | STOP-Exclude | Continue
3. Is the study an observational study of placenta previa? | Yes | No | Cannot Determine
NOTE: Case reports on placenta previa and studies on placental abruption will NOT be included | Continue | STOP-Exclude | Continue
4. Is placenta previa diagnosed in early pregnancy (first or second trimester)? | Yes | No | Cannot Determine
| STOP-Exclude | Continue | Continue
5. Are data about cesarean delivery as a risk factor for placenta previa presented? | Yes | No | Cannot Determine
| Continue | STOP-Exclude | Continue

Please check one option below based on your answers to Q1–Q5.

Pull Article□ Any combination of “Yes” and/or “Cannot Determine” is circled above

Do NOT Pull Article Any “No” is circled above

Assessment of Quality of Individual Articles for RCT's

Randomization Approach | | Randomization Implementation | | Masking of Outcome Assessors | | | Operational Definitions and Measurements
Is there description of the approach to randomization? | | Is there proven good balance with statistical significance? | | (Please circle one) | | | (Please circle one)
Yes | No | Yes | No | Good | Fair | Poor | Good | Fair | Poor
| | | | NR
Is there a fatal flaw in the approach (such as lottery cards)? | | Is there good balance achieved as shown in table? | | Notes: | | | Notes:
Yes^1^ | No | Yes | No
Explain:
Overall Randomization Approach and Implementation
| (Please circle one)
| Good ^2^ | Fair | Poor
Post-Randomization Exclusions | | Loss to Follow-up: Short-term | | Loss to Follow-up: Long-term | | | Statistical analysis
(Please circle one) | | (Please list numbers and percentages for each follow-up time point) | | (Please list numbers and percentages for each follow-up time point) | | | Please circle one)
Yes | No | T1 (describe): | | T1 (describe): | | | Good | Fair | Poor
Please describe: | | T2 (describe): | | T2 (describe): | | | NR
| | T3 (describe): | | T3 (describe): | | | Notes:
| | T4 (describe): | | T4 (describe):
Overall Quality ^ 3 ^
(Please circle one) | | GOOD | FAIR | POOR

1 If fatal flaw in randomization approach exists, overall randomization approach and implementation is poor and overall quality of the article/trial is also poor

2 Approach must be described and there must be good balance in order to achieve an overall randomization and implementation score of good

3 All component ratings must be good with minimal loss to follow-up for the article/trial to receive an overall quality rating of good. If an article has one or two fair or poor ratings, an overall quality score of fair should be assigned. If an article/trial has three or more fair or poor ratings and/or large loss to follow-up, the overall quality should be poor.

Assessment of Quality of Individual Articles for Nonrandomized Observational Cohorts

Domains | Elements | Score | Assessment (good, fair, poor)
Study design | Prospective | Yes/No | Yes=good/fair
Study Population | Description of study populations, study report
| The base population from which cohort participants were sought | Yes/No | All 3 yes= good; 2 yes and 1 NA
| The number of eligible women in that base population (a denominator) | Yes/No | 2 yes= fair
| The number of eligible women who were ultimately enrolled in the cohort | Yes/No | >2 yes= poor
Comparability of subjects | For all observational studies: | | For non-case controls, 4–5 yes = good; 2–3 yes = fair; 0–1 yes = poor
| • Specific inclusion/exclusion criteria for all groups | Yes/No
| • Criteria applied equally to all groups | Yes/No
| • Study groups comparable at baseline w/ reference to variables not unique to mode of delivery | Yes/No
| • Study groups comparable to non-participants with regard to confounding factors (study should thoroughly enumeration of the number of cohort participants, the characteristics of their birth experience, confounders, and general descriptive characteristics) | Yes/No
| Study groups comparable with regard to followup | Yes/No
| Continue below for case-control studies: | For case control studies: Good: ALL 3 Yes: Fair: 2 Yes; Poor: 0–1 Yes
| Explicit case definition | Yes/No
| Case ascertainment not influenced by exposure status | Yes/No
| Controls similar to cases except without condition of interest and with equal opportunity for exposure | Yes/No
Statistical Analysis | Overall statistics analysis | | 5–6 yes= good; 3–4 yes = fair;1–2 yes = poor
| Statistical tests appropriate | Yes/No
| Modeling and multivariate techniques and/or multiple comparisons taken into consideration | Yes/No
| Power calculation provided and sample size achieved | Yes/No
| Assessment of confounding
| • assessment of confounding and modifying factors by bivariate analysis, stratified analysis, or multivariable modeling | Yes/No
| • reporting of adjusted estimates for main effects that took into account identified confounding or modifying factors (stratified or separate analyses were acceptable for simple constructs) | Yes/No
| • presentation of adjusted results with a measure of statistical precision such as a confidence interval or P-value | Yes/No
Results | Overall results | | For panel studies, 3–4 yes=good; 2 yes=fair; 0–1 yes=poor; for single timepoint studies, yes=good/fair
| Measure of effect for outcomes and appropriate measure of precision | Yes/No
| Adequacy of follow-up for each study group, study describes
| • the number of participants in the sample at the time of followup, | Yes/No
| • analysis of how respondents differed from nonrespondents if loss exceeded 20 percent, and | Yes/No
| • absolute loss to followup >25 percent | Yes/No
Overall rating | 5 goods/fair: Good
| 3–4 good/fair: Fair
| 0–2 good/fair: Poor