# Appendix A: Exact Search Strings

Focused Search No. 1

#3 | Search “Cesarean Section”[MeSH] = | 21612
#4 | Search “Cesarean Section”[MeSH] Field: All Fields, Limits: Publication Date from 1990, English, Humans = | 8641
#7 | Search request OR elective OR planned OR pre-labor OR non-labor = | 61448
#8 | Search #4 AND #7 = | 1457
#9 | Search (“Cesarean Section/statistics and numerical data”[MeSH] OR “Cesarean Section/trends”[MeSH]) = | 2569
#10 | Search #7 AND #9 = | 282
#11 | Search #7 AND #9 Field: All Fields, Limits: Publication Date from 1990, English, Humans = | 230
#12 | Search #4 AND #7 Field: All Fields, Limits: Publication Date from 1990, English, Review, Humans = | 103
#13 | Search #4 AND #7 Field: All Fields, Limits: Publication Date from 1990, English, Meta-Analysis, Humans = | 16
#21 | Search “Epidemiologic Methods”[MeSH] OR “Randomized Controlled Trials”[MeSH] Field: All Fields = | 2165030
#22 | Search #8 AND #21 = | 799
#23 | Search #8 AND #21 Field: All Fields, Limits: Publication Date from 1990, English, Randomized Controlled Trial, Humans = | 225
#24 | Search #22 NOT #23 = | 574
#29 | Search (“Outcome Assessment (Health Care)”[MeSH] OR “Pregnancy Outcome”[MeSH]) OR “Reproductive History”[MeSH] OR “Treatment Outcome”[MeSH] OR “Outcome and Process Assessment (Health Care)”[MeSH] = | 287783
#30 | Search #29 AND #24 = | 194
#31 | Search (“Cesarean Section/adverse effects”[MeSH] OR “Cesarean Section/mortality”[MeSH]) = | 2409
#39 | Search “Risk Factors”[MeSH] OR “Fetal Death”[MeSH] OR (“Urinary Incontinence”[MeSH] OR “Urinary Incontinence, Stress”[MeSH]) OR “Respiratory Distress Syndrome, Newborn”[MeSH] OR “Pelvic Floor”[MeSH] OR (“Prolapse”[MeSH] OR “Uterine Prolapse”[MeSH] OR “Rectal Prolapse”[MeSH]) OR “Fecal =Incontinence”[MeSH] | 309733
#40 | Search #8 AND #39 = | 220
#41 | Search #31 AND #7 = | 233
#42 | Search #40 OR #41 = | 398
#43 | Search #40 OR #41 Field: All Fields, Limits: Publication Date from 1990, English, Humans = | 311
47 | Search “Urinary Incontinence”[MeSH] AND “Delivery, Obstetric”[MeSH] Limits: Publication Date from 1990, English, Humans = | 118
EMBASE Search:
Cesarean AND (Request OR Elective OR Planned OR Pre-Labor OR Non-Labor) = | | 77
(Several of these were discarded because they were not in English)
Cochrane Search:
Reviews:
Cesarean AND (Request OR Elective OR Planned OR Pre-Labor OR Non-Labor) = | | 8
Cochrane Clinical Trial Registry (Central OR CCTR)
Cesarean AND (Request OR Elective OR Planned OR Pre-Labor OR Non-Labor) = | | 59
Total, unduplicated database = | | 926

Focused Search No. 2

#3 | Search “Infant, Newborn”[MeSH]Or neonate = | 357815
#8 | Search “Cesarean Section”[MeSH] = | 21710
#9 | Search #8 AND #3 = | 7096
#15 | Search “Infant, Premature”[MeSH] = | 24780
#16 | Search #13 NOT #15 = | 930
#12 | Search (“Outcome Assessment (Health Care)”[MeSH] OR “Fatal Outcome”[MeSH] OR “Pregnancy Outcome”[MeSH]) OR (“Treatment Outcome”[MeSH] OR “Outcome and Process Assessment (Health Care)”[MeSH]) = | 300710
#13 | Search #9 AND #12 = | 1020
#22 | Search #16 AND #21 = | 71
#21 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials”[MeSH]) OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] = | 287666
#23 | Search #16 AND #21 Field: All Fields, Limits: English, Humans = | 64

Focused Search No. 3

#6 | Search “Infant, Newborn”[MeSH]OR neonate = | 357988
#8 | Search “Cesarean Section”[MeSH] = | 21716
#9 | Search #6 AND #8 = | 7098
#10 | Search infant, premature [MeSH] = | 24804
#11 | Search #9 NOT #10 = | 6541
#14 | Search (“Outcome Assessment (Health Care)”[MeSH] OR “Fatal Outcome”[MeSH] OR “Pregnancy Outcome”[MeSH]) OR (“Treatment Outcome”[MeSH] OR “Outcome and Process Assessment (Health Care)”[MeSH]) = | 301265
#15 | Search #11 AND #14 = | 930
#16 | Search #11 AND #14 Field: All Fields, Limits: English, Humans = | 730
#22 | Search “Epidemiologic Research Design”[MeSH] = | 403194
#23 | Search #22 AND #16 = | 33
#26 | Search “Delivery, Obstetric”[MeSH] OR “Extraction, Obstetrical”[MeSH] = | 40646
#27 | Search #8 AND #26 = | 21716
#28 | Search Comparative Study [mh] = | 1181123
#29 | Search #27 AND #28 = | 2667
#30 | Search epidemiologic study design = | 92338
#31 | Search #29 AND #30 = | 176
#32 | Search #29 AND #30 Field: All Fields, Limits: English, Humans = | 163
#37 | Search (“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials”[MeSH]) OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR “Single-Blind Method”[MeSH] Limits: English, Humans = | 243752
#38 | Search #37 AND #29 Limits: English, Humans = | 565
#39 | Search #31 OR #38 Limits: English, Humans = | 691
#40 | Search #39 AND #14 Limits: English, Humans = | 139

Focused Search No. 4

#6 | Search Infant, Newborn [mh] AND Cesarean Section/adverse effects [mh] = | 454
#7 | Search Infant, Newborn [mh] AND Cesarean Section/adverse effects [mh] Field: All Fields, Limits: English, Humans = | 303
#8 | Search Infant, premature [mh] = | 24809
#10 | Search #7 NOT #8 = | 282
#11 | Search #7 NOT #8 Field: All Fields, Limits: Editorial = | 7
#12 | Search #7 NOT #8 Field: All Fields, Limits: Letter = | 25
#13 | Search #7 NOT #8 Field: All Fields, Limits: Review = | 20
#14 | Search #11 OR #12 OR #13 = | 52
#15 | Search #10 NOT #14 = | 230

Focused Search No. 5

#1 | Search cesarean section | 31631
#2 | Search risk | 717885
#3 | Search #1 AND #2 | 5712
#7 | Search “Placenta Praevia/etiology”[MeSH] OR (“Placenta Accreta/epidemiology”[MeSH] OR “Placenta Accreta/etiology”[MeSH]) | 712
#8 | Search #3 AND #7 | 82
#9 | Search #3 AND #7 Field: All Fields, Limits: English, Humans | 69
#10 | Search #7 AND #2 Limits: English, Humans | 145
#11 | Search #9 OR #10 Limits: English, Humans | 145

Focused search #6: Faiz & Ananth Meta-Analysis Update: Literature Search

#9 | Search “Placenta Praevia”[MeSH]OR “Placental disorder” [tw] OR “antepartum hemorrhage” [tw] OR “antepartum bleeding” [tw] OR “uteroplacental bleeding” [tw] = | 1551
#10 | Search “maternal age” OR gravidity OR parity OR “cesarean section” OR “uterine surgery” OR “uterine instrumentation” OR “abortion” OR hypertension OR pre-eclampsia OR eclampsia OR “smoking” OR “drug use”
= | 476526
#11 | Search #9 AND #10 = | 717
#12 | Search #9 AND #10 Field: All Fields, Limits: Publication Date from 2000 to 2005 = | 145
#13 | Search #9 AND #10 Field: All Fields, Limits: Publication Date from 2000 to 2005, Review = | 13
#14 | Search #9 AND #10 Field: All Fields, Limits: Publication Date from 2000 to 2005, Meta-Analysis = | 1
#16 | Search #13 OR #14 Field: All Fields = | 14
#17 | Search #12 NOT #16 = | 131

This was the search as described in the Faiz and Ananth meta-analysis that was used as a guideline. This updated the literature through the end of May 2005.

[underlined: Faiz AS, Ananth CV.]

Etiology and risk factors for placenta previa: an overview and meta-analysis of observational studies.

J Matern Fetal Neonatal Med. 2003 Mar;13(3):175–90.

PMID: 12820840 [PubMed - indexed for MEDLINE]

Search strategy as described in the methods section: Observational studies published in the English language between January 1966 and March 2000 were potentially eligible for inclusion in this overview. Identification of such studies was based on a comprehensive MEDLINE search, as well as by identifying studies cited in the references of published papers. The MEDLINE search was based on the following medical subject headings (MeSH): placenta pr(a)evia, placental disorders, antepartum h(a)emorrhage, and antepartum and uteroplacental bleeding. The other key words used in conjunction with previa were maternal age, gravidity, parity, C(a)esarean delivery/section, uterine surgery, uterine instrumentation, abortion, spontaneous abortion, induced abortion, elective abortion, chronic hypertension, pregnancy-induced hypertension, pre-eclampsia, eclampsia, cigarette smoking and drug use....Published case reports on placenta previa and studies on placental abruption were excluded.