# Appendixes

Appendix A: Exact Search Strings

Appendix B: Sample Review Forms/Quality Rating Forms

Appendix C: Evidence Table

Appendix D: Listing of Excluded Studies

Appendix E: Acknowledgments