# Appendix G: List of Excluded Articles

Beyond guidelines: tool arms physicians with critical knowledge at the point of care. Dis Manag Advis 2002;8(1):9–12, 1. [Rec#: 173]
Capitated groups reaping benefits of EMR systems. Capitation Manag Rep 2003;10(6):81–4. [Rec#: 426]
CareGroup site takes some of the administrative hassle out of healthcare. Internet Healthc Strateg 2001;3(7):4–6. [Rec#: 421]
Computerization saves money, time, and trees. Healthc Benchmarks 2000;7(1):1–6. [Rec#: 418]
Computerized system alerts docs to costs. ED Manag 1999;11(9):100–2. [Rec#: 417]
Conversion to computerized patient records streamlines ER process, saves money. Health Care Cost Reengineering Rep 1997;2(3):37–40. [Rec#: 754]
Electronic system places patients in post-acute care. Hosp Case Manag 2003;11 (6):85–6. [Rec#: 427]
Evidence-based medicine system helps physicians order the right tests. Perform Improv Advis 2003; 7(3):40–4. [Rec#: 174]
Innovative CareEngine system roots out sub-optimal care. Dis Manag Advis 2003;9(1):9–13, 1. [Rec#: 175]
Innovative charting can slash costs, bolster efficiency, enhance quality. ED Manag 1995;7(11):121–3. [Rec#: 756]
Medication safety issue brief. Using automation to reduce errors. Part 2. Hosp Health Netw 2001; 75(2):33–4. [Rec#: 176]
New data storage system saves $20,000 per year. Healthc Benchmarks 2001;8(12):139–40, 142. [Rec#: 423]
Paperless records will improve quality. Hosp Peer Rev 2002;27(7):99–100. [Rec#: 424]
Physicians go online for electronic medical records. Data Strateg Benchmarks 2000;4(12):183–5, 177. [Rec#: 419]
Practice brief. Health informatics standards and information transfer: exploring the HIM role. American Health Information Management Association. J AHIMA 2001;72(1):68A–68D. [Rec#: 420]
What's happening in information systems technology that is reshaping health care delivery, and how might it assist in infection prevention and control? Am J Infect Control 1996;24(6):476–80. [Rec#: 178]
Adderley D, Hyde C, Mauseth P. (1997). The computer age impacts nurses. Comput Nurs.
Ahearn MD, Kerr SJ. (2003). General practitioners' perceptions of the pharmaceutical decision-support tools in their prescribing software. Med J Aust.
Al-Ubaydli M. (2004). Handheld computers. BMJ.
Allaert FA. (1996). The use of personal health information for controlling the costs of delivering health care: does the end justify the means?. Int J Biomed Comput.
Alper BS, Stevermer JJ, White DS, et al. (2001). Answering family physicians' clinical questions using electronic medical databases. J Fam Pract.
Amatayakul M. Making the case for electronic records. Health Data Manag 1997;5(5):56–7, 59, 61–3. [Rec#: 760]
Ammon D. (2002). What works: Ready, set, grow. A local practice implements electronic medical record (EMR) technology, triples patient volume and reduces per patient costs by more than 10 percent. Health Manag Technol.
Anderson B. Document imaging and workflow technology saves $1.2 million annually. Health Manag Technol 1999;20 (11):18–20, 22. [Rec#: 435]
Anderson G, Knickman JR. (2001). Changing the chronic care system to meet people's needs. Health Aff (Millwood).
Anderson HJ, Bunschoten B. Creating electronic records. A progress report. Health Data Manag 1996;4(9):36–8, 41–2, 44. [Rec#: 761]
Anderson JG. (2000). Security of the distributed electronic patient record: a case-based approach to identifying policy issues. Int J Med Inf.
Antoine W. (2002). Electronic miracle. Memorial Hermann put its patient files online and watch its revenue grow. Health Forum J.
Arikian SR, Mario GG, Doyle JJ. (1996). Building a computerized disease management operating system. Oncology (Huntingt).
Asher JR. (2003). Time and money. A look at message automation via a computerized patient record. MGMA Connex.
Atkinson JC, Zeller GG, Shah C. (2002). Electronic patient records for dental school clinics: more than paperless systems. J Dent Educ.
Aubert BA, Hamel G. (2001). Adoption of smart cards in the medical sector: the Canadian experience. Soc Sci Med.
Austin T, Iliffe S, Leaning M, et al. (1996). A prototype computer decision support system for the management of asthma. J Med Syst.
Bakken S. (2001). An informatics infrastructure is essential for evidence-based practice. J Am Med Inform Assoc.
Bakker A, Hammond E, Ball M. (1995). Summary report of observations, conclusions and recommendations. Int J Biomed Comput.
Balas EA, Stockham MG, Mitchell MA, et al. (1995). The Columbia Registry of Information and Utilization Management Trials. J Am Med Inform Assoc.
Baldwin G. CIO secrets to calculating return on investment. Health Data Manag 2000;8(7):54–9, 62–4, 66–7. [Rec#: 440]
Ball MJ, Weaver C, Abbott PA. (2003). Enabling technologies promise to revitalize the role of nursing in an era of patient safety. Int J Med Inf.
Baltzer DJ. (2002). A realistic take on tech. Hosp Health Netw.
Barnett GO, Winickoff RN, Morgan MM, et al. (1983). A computer-based monitoring system for follow-up of elevated blood pressure. Med Care.
Barrett MJ. The evolving computerized medical record, Part II. Healthc Inform 2000;17(9):83–4, 86, 88. [Rec#: 443]
Barthell EN, Pemble KR. (2003). The National Emergency Medical Extranet project. J Emerg Med.
Basch P. (1999). Data control. Primary care practice improves productivity and profitability with electronic medical system. Healthc Inform.
Bates DW. (1999). Using information systems to improve practice. Schweiz Med Wochenschr.
Bates DW, Cohen M, Leape LL, et al. (2001). Reducing the frequency of errors in medicine using information technology. J Am Med Inform Assoc.
Bates DW, Ebell M, Gotlieb E, et al. (2003). A proposal for electronic medical records in U.S. primary care. J Am Med Inform Assoc.
Bates DW, Evans RS, Murff H, et al. (2003). Detecting adverse events using information technology. J Am Med Inform Assoc.
Bates DW, Gawande AA. (2003). Improving safety with information technology. N Engl J Med.
Bates DW, Kuperman GJ, Jha A, et al. (1997). Does the computerized display of charges affect inpatient ancillary test utilization?. Arch Intern Med.
Bates DW, Makary MA, Teich JM, et al. (1998). Asking residents about adverse events in a computer dialogue: how accurate are they?. Jt Comm J Qual Improv.
Bates DW, Spell N, Cullen DJ, et al. (1997). The costs of adverse drug events in hospitalized patients Adverse Drug Events Prevention Study Group. JAMA.
Beard N, Thomas D. (1990). Realising your potential. Health Serv J.
Bellazzi R, Riva A, Montani S, et al. A webbased system for diabetes management: the technical and clinical infrastructure. Proc AMIA Symp 1998;972. [Rec#: 65]
Berg M. (1999). Patient care information systems and health care work: a sociotechnical approach. Int J Med Inf.
Bergeron BP. (2000). What price for your patient data? Medical record freeware may also become shareware. Postgrad Med.
Berkowitz LL. (1997). Breaking down the barriers. Improving physician buy-in of CPR systems. Healthc Inform.
Bingham A. (1997). Computerized patient records benefit physician offices. Healthc Financ Manage.
Birkmeyer CM, Lee J, Bates DW, et al. (2002). Will electronic order entry reduce health care costs?. Eff Clin Pract.
Birkmeyer JD, Welch HG. (1997). A reader's guide to surgical decision analysis. J Am Coll Surg.
Biskup J, Bleumer G. (1996). Cryptographic protection of health information: cost and benefit. Int J Biomed Comput.
Boger E. (2003). Electronic tracking board reduces ED patient length of stay at Indiana Hospital. J Emerg Nurs.
Brailer DJ. Translating ideals for health information technology into practice. Health Aff (Millwood) 2004;Suppl Web Exclusives:W4-318-20. [Rec#: 954]
Brassey J, Elwyn G, Price C, et al. (2001). Just in time information for clinicians: a questionnaire evaluation of the ATTRACT project. Bmj.
Breitfeld PP, Weisburd M, Overhage JM, et al. (1999). Pilot study of a point-of-use decision support tool for cancer clinical trials eligibility. J Am Med Inform Assoc.
Brender J, Nohr C, McNair P. Research needs and priorities in health informatics. Int J Med Inf 2000;58–59:257–89. [Rec#: 196]
Briggs B. Doctors sound off on I.T. concerns. Health Data Manag 2001;9(1):38–40, 42–4, 46–8. [Rec#: 451]
Briggs B. (2002). Electronic stepping stones. Health Data Manag.
Briggs B. Gathering I.T. intelligence. Health Data Manag 2001;9(4):28–32, 34, 36. [Rec#: 452]
Briscoe M. (1997). Obstacles to the use of computers in British mental health services. Psychiatr Serv.
Broude AL. (2003). Build quality by investing in technology. An interview with Alan L. Broude. Healthc Financ Manage.
Brown EG. (2003). Methods and pitfalls in searching drug safety databases utilising the Medical Dictionary for Regulatory Activities (MedDRA). Drug Saf.
Brown SH. No free lunch: institutional preparations for computer-based patient records. Proc AMIA Symp 1999;486–90. [Rec#: 456]
Brundage MD, Groome PA, Feldman-Stewart D, et al. (1997). Decision analysis in locally advanced non-small-cell lung cancer: is it useful?. J Clin Oncol.
Brushwood DB. (2003). Maximizing the value of electronic prescription monitoring programs. J Law Med Ethics.
Bundt TS. (2002). Transcription cost analysis reveals opportunities for savings, efficiencies. J AHIMA.
Burkle T, Kuch R, Passian A, et al. (1995). The impact of computer implementation on nursing work patterns: study design and preliminary results. Medinfo.
Burstin H. (2000). Traversing the digital divide. Health Aff (Millwood).
Burstin H, Clancy C. Broader adoption of information technology needed . Health Aff (Millwood) 2002;21(6):266–7; author reply 267–8. [Rec#: 959]
Bush J. Open-source software: just what the doctor ordered? Fam Pract Manag 2003;10(6):65, 69. [Rec#: 459]
Butler MA, Bender AD. Intensive care unit bedside documentation systems. Realizing cost savings and quality improvements. Comput Nurs 1999;17(1):32–8; quiz 39–40. [Rec#: 67]
Byrnes JJ. (2001). A revolutionary advance in disease management. Healthc Leadersh Manag Rep.
Cantlon G. (1999). A new proposal for cooperation in HIT development. Health Aff (Millwood).
Carlson RW, Tu SW, Lane NM, et al. Computer-based screening of patients with HIV/AIDS for clinical-trial eligibility. Online J Curr Clin Trials 1995;Doc No 179:[3347 words; 32 paragraphs]. [Rec#68]
Carroll AE, Saluja S, Tarczy-Hornoch P. Development of a Personal Digital Assistant (PDA) based client/server NICU patient data and charting system . Proc AMIA Symp 2001;100–4. [Rec#: 462]
Cartwright J, de Sylva S, Glasgow M, et al. (2002). Inaccessible information is useless information: addressing the knowledge gap. J Med Pract Manage.
Chambliss ML, Rasco T, Clark RD, et al. (2001). The mini electronic medical record: a low-cost, low-risk partial solution. J Fam Pract.
Chin HL, Krall M. (1997). Implementation of a comprehensive computer-based patient record system in Kaiser Permanente's Northwest Region. MD Comput.
Chin HL, Krall MA. (1998). Successful implementation of a comprehensive computer-based patient record system in Kaiser Permanente Northwest: strategy and experience. Eff Clin Pract.
Chin TL. Using automation to reduce medication errors. Health Data Manag 1997;5(7):74, 76, 78–83. [Rec#: 774]
Chrischilles EA, Fulda TR, Byrns PJ, et al. (2002). The role of pharmacy computer systems in preventing medication errors. J Am Pharm Assoc (Wash).
Churgin P, Strawn K. (1998). Population health management with computerized patient records. Eff Clin Pract.
Churgin PG. (1995). Computerized patient records: the patients' response. HMO Pract.
Classen DC, Burke JP, Pestotnik SL, et al. (1999). Clinical and financial impact of intravenous erythromycin therapy in hospitalized patients. Ann Pharmacother.
Classen DC, Pestotnik SL, Evans RS, et al. (1991). Computerized surveillance of adverse drug events in hospital patients. JAMA.
Coffey RM, Ball JK, Johantgen M, et al. (1997). The case for national health data standards. Health Aff (Millwood).
Coiera E. (2004). Four rules for the reinvention of health care. BMJ.
Cole L Houston S Linking outcomes management and practice improvement. Structured care methodologies: evolution and use in patient care delivery. Outcomes Manag Nurs Pract 1999;3(2):53–9; quiz 59–60. [Rec#: 208]
Connelly DP, Aller RD. (1997). Outcomes and informatics. Arch Pathol Lab Med.
Cooper CP, Williams KN, Carey KA, et al. (2004). Advertising campaign on a major internet search engine to promote colorectal cancer screening. BMJ.
Corley ST. (2003). Electronic prescribing: a review of costs and benefits. Top Health Inf Manage.
Covell DG, Uman GC, Manning PR. (1985). Information needs in office practice: are they being met?. Ann Intern Med.
Cox PM, D'Amato S, Tillotson DJ. (2001). Reducing medication errors. Am J Med Qual.
Coye MJ, Bernstein WS. (2003). Improving America's health care system by investing in information technology. Health Aff (Millwood).
Coyle GA Heinen M Scan your way to a comprehensive electronic medical record. Augment medication administration accuracy and increase documentation efficiency with bar coding technology. Nurs Manage 2002;33(12):56, 58–9. [Rec#: 469]
Coyle-Toerner P, Collins L. (2003). How the clinical customization of an EMR means good business: a case study of Queen City Physicians. J Med Pract Manage.
Cramer H Katz PA Electronic medical records: honing the competitive edge. Adm Radiol J 1996;15(2):16, 19–22. [Rec#: 776]
Cross M. Malpractice insurers endorse electronic records as a way to reduce risk. Health Data Manag 1996;4(6):67–8, 70, 72. [Rec#: 778]
Currell R Urquhart C. Nursing record systems: effects on nursing practice and health care outcomes. Cochrane Database Syst Rev 2003;( 3):CD002099. [Rec#: 212]
Dakins DR. (2001). Is the future in the cards?. Health Data Manag.
Dambro MR, Weiss BD, McClure CL, et al. (1988). An unsuccessful experience with computerized medical records in an academic medical center. J Med Educ.
Darbro DA, Eichenauer J, Darbro MJ. (2000). Computerized medical record war story: practical experiences of computer implementation at the front. J Ambul Care Manage.
Dassenko D Slowinski T. Using the CPR to benefit a business office. Healthc Financ Manage 1995;49(7):68–70, 72–3. [Rec#: 779]
Davidson EJ, Chismar WG. (1999). Planning and managing computerized order entry: a case study of IT- enabled organizational transformation. Top Health Inf Manage.
Davis D. (1997). LeMaistre A. Has your organization leveraged the benefits of a computerized patient record?. Nurs Case Manag.
Davis W. Nine years of computerized patient records in a small family practice. Fam Pract Manag 1997;4(3):69–70, 73–6. [Rec#: 781]
de Boer HC, Heijmen BJ. (2001). A protocol for the reduction of systematic patient setup errors with minimal portal imaging workload. Int J Radiat Oncol Biol Phys.
de Boer JC, Heijmen BJ. (2002). A new approach to off-line setup corrections: combining safety with minimum workload. Med Phys.
Dean JM, Vernon DD, Cook L, et al. (2001). Probabilistic linkage of computerized ambulance and inpatient hospital discharge records: a potential tool for evaluation of emergency medical services. Ann Emerg Med.
Destache CJ, Meyer SK, Bittner MJ, et al. (1990). Impact of a clinical pharmacokinetic service on patients treated with aminoglycosides: a cost-benefit analysis. Ther Drug Monit.
Destache CJ, Meyer SK, Rowley KM. (1990). Does accepting pharmacokinetic recommendations impact hospitalization? A cost-benefit analysis. Ther Drug Monit.
Detmer DE, Deering MJ. (1999). Health information: a broader view. Health Aff (Millwood).
Detmer DE. (2003). Building the national health information infrastructure for personal health health care services public health, and research. BMC Med Inform Decis Mak.
DeVore PA. (1991). Computer-assisted comprehensive geriatric assessment in a family physician's office. South Med J.
DeWitt AL, Gunn SR, Hopkins P, et al. (2004). Critical care medicine mailing list: growth of an online forum. BMJ.
Diehl M. Health system re-engineering: a CPRS economic decision model. Proc Annu Symp Comput Appl Med Care 1995;688–92. [Rec#: 783]
Dilts D, Khamalah J, Plotkin A. (1995). Using cluster analysis for medical resource decision making. Med Decis Making.
Donald JB. (1986). On line prescribing by computer. Br Med J (Clin Res Ed).
Doolan DF, Bates DW. (2002). Computerized physician order entry systems in hospitals: mandates and incentives. Health Aff (Millwood).
Dorenfest S. (2000). The decade of the '90s. Poor use of IT investment contributes to the growing healthcare crisis. Healthc Inform.
Doupnik AM. (2002). An overview of Electronic Document Management System product offerings. Top Health Inf Manage.
Dowie J. (1999). What decision analysis can offer the clinical decision maker. Why outcome databases such as KIGS and KIMS are vital sources for decision analysis. Horm Res.
Dowie R, Gregory RP, Rowsell KV, et al. A decision analytic approach to commissioning ambulance cardiac services J Manag Med 1998;12(2–3):81–91, 79. [Rec#: 223]
Doyle O. (1989). Make benefits realization part of software purchase. Mod Healthc.
Drazen E. Why don't we have computer-based patient records? J AHIMA 1996;67(6):56–8; quiz 59–60. [Rec#: 784]
In: Drazen E, Fortin J First Consulting Group. Digital hospitals move off the drawing board. 2003. [Rec#: 916]
Dujat C, Haux R, Schmucker P, et al. (1995). Digital optical archiving of medical records in hospital information systems--a practical approach towards the computer-based patient record?. Methods Inf Med.
Duke JR, Mandell SF. (1990). The benefits and perils of system integration. J Med Syst.
Durlach P. (2000). Focus on voice recognition. Talking up an emerging technology. Health Manag Technol.
Eckman MH. (2001). Patient-centered decision making: a view of the past and a look toward the future. Med Decis Making.
Edsall RL. (2000). Toward electronic medical records for the small practice. Fam Pract Manag.
Eichhorst B. (2002). Patient-centric HIS. A healthcare information system based on a longitudinal patient record provides benefits to patients--and clinicians administrators and IT staff as well. Health Manag Technol.
Elbourne D, Richardson M, Chalmers I, et al. (1987). The Newbury Maternity Care Study: a randomized controlled trial to assess a policy of women holding their own obstetric records. Br J Obstet Gynaecol.
Elson RB, Connelly DP. (1995). Computerized decision support systems in primary care. Prim Care.
Essin DJ, Lincoln TL. Implementing a low-cost computer-based patient record: a controlled vocabulary reduces data base design complexity. Proc Annu Symp Comput Appl Med Care 1995;431–5. [Rec#: 787]
Estabrooks C, Goel V, Thiel E, et al. (2001). Decision aids: are they worth it? A systematic review. J Health Serv Res Policy.
Everett JE. (2002). A decision support simulation model for the management of an elective surgery waiting system. Health Care Manag Sci.
Eytan TA, Goldberg HI. (2001). How effective is the computer-based clinical practice guideline?. Eff Clin Pract.
Fabrey RH. (1996). Physician computer order entry in a hospital setting. Physician Exec.
Feldman P, Gold M, Chu K. (1994). Enhancing information for state health policy. Health Aff (Millwood).
Feldman PH, Gold M, Chu K. (1997). State health policy information: what worked?. Health Aff (Millwood).
Ferguson GH, Hildman T, Nichols B. (1987). The effect of nursing care planning systems on patient outcomes. J Nurs Adm.
Fermann GJ. (2002). Suyama J. Point of care testing in the emergency department. J Emerg Med.
Fernando B, Savelyich BS, Avery AJ, et al. (2004). Prescribing safety features of general practice computer systems: evaluation using simulated test cases. BMJ.
Fernandopulle R, Ferris T, Epstein A, et al. (2003). A research agenda for bridging the ‘quality chasm.’. Health Aff (Millwood).
Ferner RE. (2004). Computer aided prescribing leaves holes in the safety net. BMJ.
Fieschi M, Dufour JC, Staccini P, et al. (2003). Medical decision support systems: old dilemmas and new paradigms?. Methods Inf Med.
Finfgeld DL. (1999). Computer-assisted therapy: harbinger of the 21st century?. Arch Psychiatr Nurs.
Finkelstein J, Cabrera MR, Hripcsak G. (2000). Internet-based home asthma telemonitoring: can patients handle the technology?. Chest.
Finnerty M, Altmansberger R, Bopp J, et al. (2002). Using state administrative and pharmacy data bases to develop a clinical decision support tool for schizophrenia guidelines. Schizophr Bull.
Firouzan PA, Coburn K. (1996). Research review: Survey of automation in health information management departments. Top Health Inf Manage.
Fischer S, Stewart TE, Mehta S, et al. (2003). Handheld computing in medicine. J Am Med Inform Assoc.
Fleisher GR. (1997). What works. Children's Hospital ER automates records to save lives and money. Health Manag Technol.
Fletcher J, Hicks NR, Kay JD, et al. (1995). Using decision analysis to compare policies for antenatal screening for Down's syndrome. Bmj.
Fordham D, McPhee SJ, Bird JA, et al. (1990). The Cancer Prevention Reminder System. MD Comput.
Fors UG, Sandberg HC. (2001). Computer-aided risk management--a software tool for the Hidep model. Quintessence Int.
Foster RA, Antonelli PJ. Computerized physician-order entry: are we there yet? Otolaryngol Clin North Am 2002;35(6):1237–43, vii. [Rec#: 485]
Frame PS. (1995). Computerized health maintenance tracking systems: a clinician's guide to necessary and optional features. A report from the American Cancer Society Advisory Group on Preventive Health Care Reminder Systems. J Am Board Fam Pract.
Fretschner R, Bleicher W, Heininger A, et al. (2001). Patient data management systems in critical care. J Am Soc Nephrol.
Frijling BD, Lobo CM, Hulscher ME, et al. (2002). Multifaceted support to improve clinical decision making in diabetes care: a randomized controlled trial in general practice. Diabet Med.
Frisse ME. (1998). Computers and productivity: is it time for a reality check?. Acad Med.
Gadd CS, Baskaran P, Lobach DF. Identification of design features to enhance utilization and acceptance of systems for Internet-based decision support at the point of care. Proc AMIA Symp 1998;91–5. [Rec#: 239]
Gardner E. (1990). Quantifying system benefits an elusive task. Mod Healthc.
Gawande AA, Bates DW. (2000). The use of information technology in improving medical performance. Part II. Physician-support tools. MedGenMed.
Gawande AA, Bates DW. (2000). The use of information technology in improving medical performance. Part III. Patient-support tools. MedGenMed.
Gentile D. (2003). Toward growth in transcription solutions. Healthcare providers can gain minutes and even hours of efficiency with transcription technology. Health Manag Technol.
Gillespie G. CIOs making soft sell when calculating ROI. Health Data Manag 2002;10(8):44–8, 50. [Rec#: 491]
Gillespie G. In paper war, is OCR a good soldier? Health Data Manag 2003;11(10):58–60, 62 64, passim. [Rec#: 492]
Gillespie G. (2000). Online clinical guidelines help trim costs. Health Data Manag.
Glandon GL, Shapiro RJ. (1988). Benefit-cost analysis of hospital information systems: the state of the (non) art. J Health Hum Resour Adm.
Glowinski A. (1995). Integrating guidelines and the clinical record: the role of semantically constrained terminologies. Stud Health Technol Inform.
Goddard BL. (2000). Termination of a contract to implement an enterprise electronic medical record system. J Am Med Inform Assoc.
Goedert J. (2003). Practice talks up substantial ROI. Health Data Manag.
Goldsmith J, Blumenthal D, Rishel W. (2003). Federal health information policy: a case of arrested development. Health Aff (Millwood).
Goldstein MK, Coleman RW, Tu SW, et al. (2004). Translating research into practice: organizational issues in implementing automated decision support for hypertension in three medical centers. J Am Med Inform Assoc.
Goodman KW. (1996). Critical care computing: outcomes, confidentiality, and appropriate use. Crit Care Clin.
Gordon C. (1995). Practice guidelines and healthcare telematics: towards an alliance. Stud Health Technol Inform.
Gordon C, Gray JA, Toth B, et al. (2000). Systems of evidence-based healthcare and personalised health information: some international and national trends. Stud Health Technol Inform.
Gorman C, Looker J, Fisk T, et al. (1996). A clinically useful diabetes electronic medical record: lessons from the past; pointers toward the future. Eur J Endocrinol.
Grams RR, Morgan G. (1999). Medical record innovations that can improve physician productivity. J Med Syst.
Grams RR, Moyer EH. (1997). The search for the elusive electronic medical record system--medical liability, the missing factor. J Med Syst.
Granados A. (1999). Health technology assessment and clinical decision making: which is the best evidence?. Int J Technol Assess Health Care.
Grandinetti D. The good news--and bad--about Web-based EMRs. Med Econ 2000;77(17):73–4, 77, 80 passim. [Rec#: 501]
Greatbatch D, Heath C, Campion P, et al. (1995). How do desk-top computers affect the doctor-patient interaction?. Fam Pract.
Green J, Wintfeld N. (1993). How accurate are hospital discharge data for evaluating effectiveness of care?. Med Care.
Greene J. The portal advantage. Hospitals lure docs with easy access to medical records. Hosp Health Netw 2001;75 (10):56–8, 2. [Rec#: 502]
Greene ZB. (2002). Creating and managing a paperless health information management department. Top Health Inf Manage.
Greengold NL. (2002). A Web-based program for implementing evidence-based patient safety recommendations. Jt Comm J Qual Improv.
Greenhalgh T, Hughes J, Humphrey C, et al. (2002). A comparative case study of two models of a clinical informaticist service. Bmj.
Grimshaw JM, Russell IT. (1994). Achieving health gain through clinical guidelines II: Ensuring guidelines change medical practice. Qual Health Care.
Hagland M. Finding the e in healthcare. Healthc Inform 2001;18(11):21–4, 26. [Rec#: 506]
Hagland M. Moving gradually toward a paperless world. J AHIMA 2000;71(8):26–31; quiz 33–4. [Rec#: 504]
Hagland M. (1997). Outpatient clinics without the paperwork. Health Manag Technol.
Halley EC, Kambic PM. (1996). Concurrent process redesign and clinical documentation system implementation: a 6-month success story. Top Health Inf Manage.
Halpern MT, Palmer CS, Simpson KN, et al. (1998). The economic and clinical efficiency of point-of-care testing for critically ill patients: a decision-analysis model. Am J Med Qual.
Hancock WM, Walter PF. (1986). Reduce hospital costs with admissions and operating room scheduling systems. Softw Healthc.
Hannan TJ. (1999). Detecting adverse drug reactions to improve patient outcomes. Int J Med Inf.
Hannan TJ. (1999). Variation in health care--the roles of the electronic medical record. Int J Med Inf.
Hansen B. Handheld computers in diabetes management. Diabetes Self Manag 2002;19(6):43–4, 46, 48–9. [Rec#: 509]
Hanson CW, Marshall BE. (2001). Artificial intelligence applications in the intensive care unit. Crit Care Med.
Harman J. (1998). Topics for our times: new health care data--new horizons for public health. Am J Public Health.
Hart JT, Thomas C, Gibbons B, et al. (1991). Twenty five years of case finding and audit in a socially deprived community. BMJ.
Hasenfeld R, Shekelle PG. (2003). Is the methodological quality of guidelines declining in the US? Comparison of the quality of US Agency for Health Care Policy and Research (AHCPR) guidelines with those published subsequently. Qual Saf Health Care.
Hassey A, Gerrett D, Wilson A. (2001). A survey of validity and utility of electronic patient records in a general practice. Bmj.
Heinrichs W, Monk S, Eberle B. (1997). [Automated anesthesia record systems]. Anaesthesist.
Hellbruck RP. (2000). [Electronic data processing assisted quality management in general practice networks]. Gesundheitswesen.
Henry SB. (1995). Nursing informatics: state of the science. J Adv Nurs.
Henry SB, Douglas K, Galzagorry G, et al. (1998). A template-based approach to support utilization of clinical practice guidelines within an electronic health record. J Am Med Inform Assoc.
Henry SB, Mead CN. (1997). Nursing classification systems: necessary but not sufficient for representing “what nurses do” for inclusion in computer-based patient record systems. J Am Med Inform Assoc.
Hicks J, Waldrum M, Wilson V, et al. (2000). Transcription system overhaul reaps savings, efficiency. J AHIMA.
Hodgkins ML. (1995). Are you ready for the computer-based patient record?. J Ambul Care Manage.
Hoffer A. (2003). BPM: antidote to inefficiency. Business process management serves as a foundation for effective workflow automation in healthcare. Health Manag Technol.
Hoffman C, Rice D, Sung HY. (1996). Persons with chronic conditions. Their prevalence and costs. JAMA.
Hofmans-Okkes IM, Lamberts H. (1996). The International Classification of Primary Care (ICPC): new applications in research and computer-based patient records in family practice. Fam Pract.
Holmes-Rovner M, Kroll J, Rovner DR, et al. (1999). Patient decision support intervention: increased consistency with decision analytic models. Med Care.
Holzman TG, Griffith A, Hunter WG, et al. Computer-assisted trauma care prototype. Medinfo 1995;8 Pt 2:1685. [Rec#: 261]
Homer CS, Davis GK, Everitt LS. (1999). The introduction of a woman-held record into a hospital antenatal clinic: the bring your own records study. Aust N Z J Obstet Gynaecol.
Hovenga EJ. (2001). Nursing information and the use of electronic health records. Aust Nurs J.
Howard WR. (2003). Development of an affordable data collection, reporting, and analysis system. Respir Care.
Hozo I, Djulbegovic B. (1999). Using the Internet to calculate clinical action thresholds. Comput Biomed Res.
Hughes KK, Dvorak EM. (1997). The use of decision analysis to examine ethical decision making by critical care nurses. Heart Lung.
Hurley SF, Dziukas LJ, McNeil JJ, et al. (1986). A randomized controlled clinical trial of pharmacokinetic theophylline dosing. Am Rev Respir Dis.
Hynes DM, Perrin RA, Rappaport S, et al. (2004). Informatics resources to support health care quality improvement in the veterans health administration. J Am Med Inform Assoc.
Jacobs I. (2003). What works. Never going back. New Jersey ophthalmology practice moves from paper charts to an EMR system. Health Manag Technol.
Jadad AR. (2002). Evidence-based decision making and asthma in the internet age: the tools of the trade. Allergy.
Jadad AR, Haynes RB, Hunt D, et al. (2000). The Internet and evidence-based decision-making: a needed synergy for efficient knowledge management in health care. CMAJ.
Jantos LD, May RR, Sheppard RL. (1998). Streamlining medical group operations through an integrated computer-based patient record. J Healthc Inf Manag.
Javitt JC. How to succeed in health information technology. Health Aff (Millwood) 2004;Suppl Web Exclusives:W4-321-4. [Rec#: 955]
Joch A. (2000). EMR the web way. Hosp Pract (Off Ed).
Johnson KB. (2001). Barriers that impede the adoption of pediatric information technology. Arch Pediatr Adolesc Med.
Johnson KB, Cowan J. (2002). Clictate: a computer-based documentation tool for guideline-based care. J Med Syst.
Joosting AC. (2001). Practice administration--a cost-effective option. S Afr Med J.
Jue J, Jerant AF. (2001). Electronic paper & pencil: 6 easy steps to a low-cost electronic medical record. Fam Pract Manag.
Kadas RM. (2002). The computer-based patient record is on its way. HMOs, the economy and HIPAA will drive adoption. Healthc Inform.
Kahn RA. Beyond HIPAA: the complexities of electronic record management. J AHIMA 2003;74(4):31–6; quiz 37–8. [Rec#: 525]
Kantor GS, Wilson WD, Midgley A. Open-source software and the primary care EMR. J Am Med Inform Assoc 2003;10(6):616; author reply 617. [Rec#: 526]
Kaplan B. (1995). An evaluation model for clinical information systems: clinical imaging systems. Medinfo.
Kaplan B, Lundsgaarde HP. (1996). Toward an evaluation of an integrated clinical imaging system: identifying clinical benefits. Methods Inf Med.
Katikireddi SV. (2004). HINARI: bridging the global information divide. BMJ.
Kaufman DR, Patel VL, Hilliman C, et al. (2003). Usability in the real world: assessing medical information technologies in patients' homes. J Biomed Inform.
Kazanjian A, Green CJ. (2002). Beyond effectiveness: the evaluation of information systems using A Comprehensive Health Technology Assessment Framework. Comput Biol Med.
Keller LS, McDermott S, Alt-White A. Effects of computerized nurse careplanning on selected health care effectiveness measures. Proc Annu Symp Comput Appl Med Care 1991;38–42. [Rec#: 667]
Kelly B. (2002). The future of card technology in health care. Health Data Manag.
Kelly G. (2000). Electronics, clinicians, and the NHS. BMJ.
Kelly JT. (1998). ‘After the chaos’: expected benefits of health information management. Health Aff (Millwood).
Kemper DW, Mettler M. (2002). Information therapy: a tale. Health Forum J.
Kendall DB, Levine SR. (1998). Pursuing the promise of an information-age health care system. Health Aff (Millwood).
Kerkoulas PS. (2002). How to produce EDMS requirements and cost-benefit data. Top Health Inf Manage.
Kerr EA, Krein SL, Vijan S, et al. (2001). Avoiding pitfalls in chronic disease quality measurement: a case for the next generation of technical quality measures. Am J Manag Care.
Kerr EA, Smith DM, Hogan MM, et al. (2003). Building a better quality measure: are some patients with ‘poor quality’ actually getting good care?. Med Care.
Khabir J. (1997). What works. Handheld PCs, CPR software help clinic cuts costs, enhance service. Health Manag Technol.
Khoury AT. (1998). Support of quality and business goals by an ambulatory automated medical record system in Kaiser Permanente of Ohio. Eff Clin Pract.
Kim MI, Johnson KB. (2002). Personal health records: evaluation of functionality and utility. J Am Med Inform Assoc.
Kinyon CC. (2003). One CFO's success with transitioning to an automated patient record. Healthc Financ Manage.
Kirkby KC, Lambert TJ. (1996). Computer aids to treatment in psychiatry. Aust N Z J Psychiatry.
Kleinke JD. (2000). Vaporware.com: the failed promise of the health care Internet. Health Aff (Millwood).
Kleinke JD. (1998). Release 0.0: clinical information technology in the real world. Health Aff (Millwood).
Kloss L. (2003). An electronic emergency. We need to push the industry toward standardized digital medical records. Mod Healthc.
Kluge EH. (2000). Professional codes for electronic HC record protection: ethical, legal, economic and structural issues. Int J Med Inf.
Kok MR, Boon ME. (1996). Consequences of neural network technology for cervical screening: increase in diagnostic consistency and positive scores. Cancer.
Koppel R, Metlay JP, Cohen A, et al. (2005). Role of computerized physician order entry systems in facilitating medication errors. JAMA.
Krall MA, Chin H, Dworkin L, et al. (1997). Improving clinician acceptance and use of computerized documentation of coded diagnosis. Am J Manag Care.
Krobock JR. (1984). A taxonomy: hospital information systems evaluation methodologies. J Med Syst.
Krohn R. (2002). Picture archiving and computing systems: the key to enterprise digital imaging. Manag Care Interface.
Kuebler KK, Bruera E. (2000). Interactive collaborative consultation model in end-of-life care. J Pain Symptom Manage.
Kuntz KM, Tsevat J, Weinstein MC, et al. (1999). Expert panel vs decision-analysis recommendations for postdischarge coronary angiography after myocardial infarction. Jama.
Kuperman GJ, Gibson RF. (2003). Computer physician order entry: benefits, costs, and issues. Ann Intern Med.
Kuperman GJ, Teich JM, Gandhi TK, et al. (2001). Patient safety and computerized medication ordering at Brigham and Women's Hospital. Jt Comm J Qual Improv.
Kuruvilla S, Dzenowagis J, Pleasant A, et al. (2004). Digital bridges need concrete foundations: lessons from the Health InterNetwork India. BMJ.
Laerum H, Ellingsen G, Faxvaag A. (2001). Doctors' use of electronic medical records systems in hospitals: cross sectional survey. Bmj.
Laing K. (2002). The benefits and challenges of the computerized electronic medical record. Gastroenterol Nurs.
Lakhani AD, Avery A, Gordon A, et al. (1984). Evaluation of a home based health record booklet. Arch Dis Child.
Lambrinoudakis C, Gritzalis S. (2000). Managing medical and insurance information through a smart-card-based information system. J Med Syst.
Landis SE, Hulkower SD, Pierson S. (1992). Enhancing adherence with mammography through patient letters and physician prompts. A pilot study. N C Med J.
Langton KB, Horsman J, Hayward RS, et al. A Clinical Informatics Network (CLINT) to support the practice of evidence-based health care. Proc AMIA Annu Fall Symp 1996;428–32. [Rec#: 281]
Latimer EW. (1999). Assessing the impact of ambulatory computer-based medical record systems. MD Comput.
Lawler F, Cacy JR, Viviani N, et al. (1996). Implementation and termination of a computerized medical information system. J Fam Pract.
Lazarus R, Kleinman KP, Dashevsky I, et al. (2001). Using automated medical records for rapid identification of illness syndromes (syndromic surveillance): the example of lower respiratory infection. BMC Public Health.
Lazarus SS. (1999). Physicians' use of electronic medical records--identifying and crossing the barriers. Med Group Manage J.
Leape LL, Bates DW, Cullen DJ, et al. (1995). Systems analysis of adverse drug events. ADE Prevention Study Group. JAMA.
Leape LL, Berwick DM, Bates DW. (2002). What practices will most improve safety? Evidence-based medicine meets patient safety. JAMA.
Lee FW. (1996). Can computer-aided systems engineering tools enhance the development of health care information systems? A critical analysis. Top Health Inf Manage.
Lee IN, Lee SC, Embrechts M. (2002). Important variable selection techniques with multiple solutions for medical information applications. Med Inform Internet Med.
Lee ML, Warner HR. (1992). Performance of a diagnostic system (Iliad) as tool for quality assurance. Comput Biomed Res.
Lehmann ED, Deutsch T. (1995). Application of computers in diabetes care--a review. I. Computers for data collection and interpretation. Med Inform (Lond).
Lehmann ED, Deutsch T. (1995). Application of computers in diabetes care--a review. II. Computers for decision support and education. Med Inform (Lond).
Leipzig M. (1996). Implementing an electronic medical record system in ambulatory care. Hosp Technol Ser.
Lenert LA, Cher DJ. (1999). Use of meta-analytic results to facilitate shared decision making. J Am Med Inform Assoc.
Lepage EF, Gardner RM, Laub RM, et al. (1992). Improving blood transfusion practice: role of a computerized hospital information system. Transfusion.
Lester J, Prady S, Finegan Y, et al. (2004). Learning from e-patients at Massachusetts General Hospital. BMJ.
Liang MH, Shadick N. (1997). Feasibility and utility of adding disease-specific outcome measures to administrative databases to improve disease management. Ann Intern Med.
Liederman EM, Morefield CS. (2003). Web messaging: A new tool for patient-physician communication. J Am Med Inform Assoc.
Lillehaug SI, Lajoie SP. (1998). AI in medical education--another grand challenge for medical informatics. Artif Intell Med.
Linney B. (2003). Cardiology practice proves that electronic medical records do raise revenue. Physician Exec.
Lipton HL, Miller RH, Wimbush JJ. (2003). Electronic prescribing: ready for prime time?. J Healthc Inf Manag.
Liu BJ, Cao F, Zhou MZ, et al. (2003). Trends in PACS image storage and archive. Comput Med Imaging Graph.
Long PW, Larkins RG, Patterson CG, et al. (2001). Facilitating best practice: transferring the lessons of the Clinical Support Systems Program. J Qual Clin Pract.
Lowenstein E, Greenberg D. (1996). Next-generation informatics. A new picture of quality medicine. Physician Exec.
Lowes B. (2003). Firewalls: cheap and easy protection. Med Econ.
Lowes R. (2003). Build an EMR for next to nothing. Med Econ.
Lowes R. (2002). EMR? Not exactly. Good enough? For now. Med Econ.
Lowes R. They're still working on the electronic medical record. Med Econ 2000;77(13):29–32, 38. [Rec#: 548]
Lowes R. (2002). Toward a handheld EMR. Med Econ.
Lubarsky DA, Sanderson IC, Gilbert WC, et al. (1997). Using an anesthesia information management system as a cost containment tool. Description and validation. Anesthesiology.
Lumpkin JR, Richards MS. (2002). Transforming the public health information infrastructure. Health Aff (Millwood).
Luxenberg SN, DuBois DD, Fraley CG, et al. Electronic forms: benefits drawbacks of a World Wide Web-based approach to data entry. Proc AMIA Annu Fall Symp 1997 804–8. [Rec#: 813]
Maglaveras N, Koutkias V, Chouvarda I, et al. (2002). Home care delivery through the mobile telecommunications platform: the Citizen Health System (CHS) perspective. Int J Med Inf.
Mahoney ME. (2002). Transforming health information management through technology. Top Health Inf Manage.
Major LF Turner MG. Assessing the information management requirements for behavioral health providers. J Healthc Manag 2003;48(5):323–33; discussion 334–5. [Rec#: 552]
Makela M, Kunnamo L. (2001). Implementing evidence in Finnish primary care. Use of electronic guidelines in daily practice. Scand J Prim Health Care.
Mandl KD, Kohane IS, Brandt AM. (1998). Electronic patient-physician communication: problems and promise. Ann Intern Med.
Marill KA, Gauharou ES, Nelson BK, et al. (1999). Prospective, randomized trial of template-assisted versus undirected written recording of physician records in the emergency department. Ann Emerg Med.
Markle Foundation The Robert Wood Johnson Foundation. Financial, legal and organizational approaches to achieving electronic connectivity in healthcare: working group on financial, organizational, and legal sustainability of health information exchange. 2004. [Rec# 951]
Marks I. (1996). A computerized system to measure treatment outcomes and cost. Psychiatr Serv.
Martin-Baranera M, Planas I, Palau J, et al. (1995). IMASIS computer-based medical record project: dealing with the human factor. Medinfo.
Masys DR. (2002). Effects of current and future information technologies on the health care workforce. Health Aff (Millwood).
Matchar DB, Samsa GP. (1999). Using outcomes data to identify best medical practice: the role of policy models. Hepatology.
Mathieson S. (2003). For a few dollars more. Health Serv J.
Mathis R Doyle S. A quality mix: using evidence and experience to evaluate new technologies. J Healthc Qual 2003;25(5):4–6; quiz 6–7. [Rec#: 297]
Matthews P. (2000). Planning for successful outcomes in the new millennium. Top Health Inf Manage.
May S. (2002). A CPR system can grow a practice. Improved efficiencies in charting and workflow allow better and faster healthcare delivery. Healthc Inform.
McAlearney AS, Schweikhart SB, Medow MA. (2004). Doctors' experience with handheld computers in clinical practice: qualitative study. BMJ.
McArthur J, Dickinson A. (1999). Decision making the explicit evidence-based way: comparing benefits, harms and costs. Nurs Prax N Z.
McCormick K, Renner AL, Mayes R, et al. (1997). The federal and private sector roles in the development of minimum data sets and core health data elements. Comput Nurs.
McCormick KA. (1995). Including oncology outcomes of care in the computer-based patient record. Oncology (Huntingt).
McDonald CJ. (1998). Need for standards in health information. Health Aff (Millwood).
McDonald CJ, Overhage JM, Mamlin BW, et al. (2004). Physicians, information technology, and health care systems: a journey, not a destination. J Am Med Inform Assoc.
McDonald CJ, Overhage JM, Dexter P, et al. (1998). What is done, what is needed and what is realistic to expect from medical informatics standards. Int J Med Inf.
McDonald CJ, Overhage JM, Tierney WM, et al. (1999). The Regenstrief Medical Record System: a quarter century experience. Int J Med Inf.
McGlynn EA, Asch SM, Adams J, et al. (2003). The quality of health care delivered to adults in the United States. N Engl J Med.
McGowan JJ, Winstead-Fry P. (1999). Problem Knowledge Couplers: reengineering evidence-based medicine through interdisciplinary development, decision support, and research. Bull Med Libr Assoc.
McKenzie NC, Marks IM. (1997). Overcoming interface problems in computerized monitoring of clinical outcomes. MD Comput.
McPhee SJ, Bird JA, Jenkins CN, et al. (1989). Promoting cancer screening. A randomized, controlled trial of three interventions. Arch Intern Med.
McQueen L, Mittman BS, Demakis JG. (2004). Overview of the Veterans Health Administration (VHA) Quality Enhancement Research Initiative (QUERI). J Am Med Inform Assoc.
Mehta V, Kushniruk A, Gauthier S, et al. (1998). Use of evidence in the process of practice change in a clinical team: a study-forming part of the Autocontrol Project. Int J Med Inf.
Memel DS, Scott JP, McMillan DR, et al. (2001). Development and implementation of an information management and information technology strategy for improving healthcare services: a case study. J Healthc Inf Manag.
Mendelson DN, Goodman CS, Ahn R, et al. (1998). Outcomes and effectiveness research in the private sector. Health Aff (Millwood).
Mendelson DN, Salinsky EM. (1997). Health information systems and the role of state government. Health Aff (Millwood).
Merkouris AV. (1995). Computer-based documentation and bedside terminals. J Nurs Manag.
Messina E. (1995). Eliminating serious risks in the outpatient clinic with an electronic medical record. J Healthc Risk Manag.
Metfessel BA. (2001). An automated tool for an analysis of compliance to evidence-based clinical guidelines. Medinfo.
Meyer K, Dimond M, Shaver J, et al. (1995). The ‘Learnmore’ project: information acquisition solutions for the long-term care information system. Medinfo.
Meyer TJ, Van Kooten D, Marsh S, et al. (1991). Reduction of polypharmacy by feedback to clinicians. J Gen Intern Med.
Michael P, Pritchett E. (2001). The impact of HIPAA electronic transmissions and health information privacy standards. J Am Diet Assoc.
Middleton G. (2002). The electronic revolution. Report writing in the 21st century. Emerg Med Serv.
Mildon J, Cohen T. Drivers in the electronic medical records market. Health Manag Technol 2001;22(5):14–6, 18. [Rec#: 561]
Miller RH, Sim I. (2004). Physicians' use of electronic medical records: barriers and solutions. Health Aff (Millwood).
Miller RA, Gardner RM. (1997). Recommendations for responsible monitoring and regulation of clinical software systems. American Medical Informatics Association, Computer-based Patient Record Institute, Medical Library Association, Association of Academic Health Science Libraries, American Health Information Management Association, American Nurses Association. J Am Med Inform Assoc.
Miller RA, Gardner RM. (1997). Summary recommendations for responsible monitoring and regulation of clinical software systems. American Medical Informatics Association The Computer-based Patient Record Institute, The Medical Library Association, The Association of Academic Health Science Libraries, The American Health Information Management Association, and The American Nurses Association. Ann Intern Med.
Miller SR, I think I scan. Case study: implementing the computerized patient record--not an EMR. MGMA Connex 2003;3(2):46–9, 1. [Rec#: 562]
Miller TE, Derse AR. (2002). Between strangers: the practice of medicine online. Health Aff (Millwood).
Millonig MK, Jackson TL, Ellis WM. (2002). Improving medication use through pharmacists' access to patient-specific health care information. J Am Pharm Assoc (Wash).
Milstein A, Galvin RS, Delbanco SF, et al. (2000). Improving the safety of health care: the leapfrog initiative. Eff Clin Pract.
Mitchell RD, Jessup S. Staying one step ahead--development of an electronic record. Caring 1995;14(8):34,37, 39–41. [Rec#: 818]
Moehr JR. (1998). Informatics in the service of health a look to the future. Methods Inf Med.
Mohr DN. (1997). Benefits of an electronic clinical information system. Healthc Inf Manage.
Moidu K, Wigertz O, Trell E. (1992). Multi centre systems analysis study of primary health care: a study of socio-organizational and human factors. Int J Biomed Comput.
Monane M, Matthias DM, Nagle BA, et al. (1998). Improving prescribing patterns for the elderly through an online drug utilization review intervention: a system linking the physician, pharmacist, and computer. JAMA.
Montoya ID, Carlson JW. (1996). Point-of-care systems informatics, and health care delivery. Health Care Superv.
Moran DW. (1998). Health information policy: on preparing for the next war. Health Aff (Millwood).
Morris AH. (2002). Decision support and safety of clinical environments. Qual Saf Health Care.
Morris AH. (2001). Rational use of computerized protocols in the intensive care unit. Crit Care.
Morrissey J. Out to set the record. With a push from HHS the effort to create electronic medical records continues to build momentum. Mod Healthc 2003;33(42):28–32, 35. [Rec#: 563]
Muller CR. (2002). Computer applications in the search for unrelated stem cell donors. Transpl Immunol.
Mullooly JP. (1996). Misclassification model for person-time analysis of automated medical care databases. Am J Epidemiol.
Munter KH, Schenk JF, Thrun F, et al. (1999). The “Phoenix” ADR database of the Drug Commission of the German Medical Profession--a clinically useful approach to optimize evidence-based medicine in Germany. Semin Thromb Hemost.
Murray D. Electronic records solved this practice's problems. Med Econ 1996;73(10):135–6, 142–4, 147. [Rec#: 823]
Neame R. (1997). Smart cards--the key to trustworthy health information systems. BMJ.
Nenov V, Klopp J. (1996). Remote analysis of physiological data from neurosurgical ICU patients. J Am Med Inform Assoc.
Nerenz DR. (2001). Capacities and limitations of information systems as data sources on quality of care at the end of life. J Pain Symptom Manage.
Nicolosi E, Molino F, Molino G. (1996). Computerized approach to active and objective quality control of patient care. Int J Biomed Comput.
Nilsson G, Ahlfeldt H, Strender LE. (2002). Computerisation, coding, data retrieval and related attitudes among Swedish general practitioners-a survey of necessary conditions for a database of diseases and health problems. Int J Med Inf.
Nixon SJ, Munro MM, Sands I, et al. (2000). Is Intranet technology the low cost, quick fix solution for Scotland's clinical information technology chaos? Results of a pilot study. Scott Med J.
Njalsson T. (1995). On content of practice. The advantage of computerized information systems in family practice. Scand J Prim Health Care.
Norrie P, Blackwell RE. (2000). Constructing a financial case for a computerized patient data management system (PDMS) in a cardiothoracic intensive care unit. Med Inform Internet Med.
O'Brien L. (2003). Setting the standard. West Coast healthcare network mandates ERP system to ensure business standardization in four states. Health Manag Technol.
O'Connell RT, Cho C, Shah N, et al. (2004). Take note(s): differential EHR satisfaction with two implementations under one roof. J Am Med Inform Assoc.
O'Connor AM, Rostom A, Fiset V, et al. (1999). Decision aids for patients facing health treatment or screening decisions: systematic review. Bmj.
O'Connor AM, Stacey D, Entwistle V, et al. Decision aids for people facing health treatment or screening decisions. Cochrane Database Syst Rev 2003;(2):CD001431. [Rec#: 327]
O'Connor K. Information management for managed care. Med Group Manage J 1995;42(6):52–4, 56, 75. [Rec#: 829]
O'Neil AC, Petersen LA, Cook EF, et al. (1993). Physician reporting compared with medical-record review to identify adverse medical events. Ann Intern Med.
Ohno-Machado L, Wang SJ, Mar P, et al. Decision support for clinical trial eligibility determination in breast cancer. Proc AMIA Symp 1999;340–4. [Rec#: 100]
Oostendorp A, Hoekstra S, Aarts J. (1998). Exploring factors required for successful implementation of healthcare informatics. Stud Health Technol Inform.
Ornstein S, Bearden A. (1994). Patient perspectives on computer-based medical records. J Fam Pract.
Ornstein SM. (2001). Translating research into practice using electronic medical records the PPRNet-TRIP project: primary and secondary prevention of coronary heart disease and stroke. Top Health Inf Manage.
Ornstein SM, Garr DR, Jenkins RG. (1993). A comprehensive microcomputer-based medical records system with sophisticated preventive services features for the family physician. J Am Board Fam Pract.
Orson J. (2000). Using the Internet to enhance evidence-based practice. Br J Perioper Nurs.
Overhage JM, Middleton B, Miller RA, et al. (2002). Does national regulatory mandate of provider order entry portend greater benefit than risk for health care delivery? The 2001 ACMI debate. The American College of Medical Informatics. J Am Med Inform Assoc.
Overhage JM, Tierney WM, McDonald CJ. (1995). Design and implementation of the Indianapolis Network for Patient Care and Research. Bull Med Libr Assoc.
Owen RR, Thrush CR, Cannon D, et al. (2004). Use of electronic medical record data for quality improvement in schizophrenia treatment. J Am Med Inform Assoc.
Owens DK. (2002). Analytic tools for public health decision making. Med Decis Making.
Ozbolt JG. (1997). From minimum data to maximum impact: using clinical data to strengthen patient care. MD Comput.
Pace MA. (2003). At home with coding. Western healthcare system improves revenue cycle management via home coders. Health Manag Technol.
Pakpahan R, Balas EA, Boren SA. Computable decision modules for patient safety in child health care. Proc AMIA Symp 2002;592–6. [Rec#: 333]
Papaconstantinou C, Theocharous G, Mahadevan S. (1998). An expert system for assigning patients into clinical trials based on Bayesian networks. J Med Syst.
Parente ST. (1997). Proprietary data systems: help or hindrance?. Health Aff (Millwood).
Parker B, Harman A. (2003). No boundaries. Advanced telecom solutions enable secure storage and transfer of electronic medical records over great distances. Health Manag Technol.
Parker RM, Ratzan SC, Lurie N. (2003). Health literacy: a policy challenge for advancing high-quality health care. Health Aff (Millwood).
Parmigiani G. (2002). Measuring uncertainty in complex decision analysis models. Stat Methods Med Res.
Pavlin JA. (2003). Investigation of disease outbreaks detected by “syndromic” surveillance systems. J Urban Health.
Pavlopoulos S, Berler A, Kyriacou E, et al. (1998). Design and development of a multimedia database for emergency telemedicine. Technol Health Care.
Pawlson G. Information technologies and the health care workforce. Health Aff (Millwood) 2002;21(6):266; author reply 267–8. [Rec#: 960]
Pennachio DL. (2003). Saving way more than a buck or two. Med Econ.
Persson M, Bohlin J, Eklund P. (2000). Development and maintenance of guideline-based decision support for pharmacological treatment of hypertension. Comput Methods Programs Biomed.
Petersen LA, Brennan TA, O'Neil AC, et al. (1994). Does housestaff discontinuity of care increase the risk for preventable adverse events?. Ann Intern Med.
Petrick N, Sahiner B, Chan HP, et al. (2002). Breast cancer detection: evaluation of a mass-detection algorithm for computer-aided diagnosis -- experience in 263 patients. Radiology.
Philp I, Goddard A, Connell NA, et al. (1994). Development and evaluation of an information system for quality assurance. Age Ageing.
Piccoli A. (2000). Elementary clinical decision analysis in evidence-based nephrology. J Nephrol.
Pifer EA, Smith S, Keever GW. (2001). EMR to the rescue. An ambulatory care pilot project shows that data sharing equals cost shaving. Healthc Inform.
Pincus HA, McQueen L. (1996). The computer age: beware the loss of the narrative. Gen Hosp Psychiatry.
Pliskin N, Glezerman M, Modai I, et al. (1996). Spreadsheet evaluation of computerized medical records: the impact on quality, time, and money. J Med Syst.
Pollack R. (1997). What works. Computerized patient record cuts redundant documentation improves charting. Health Manag Technol.
Poon EG, Blumenthal D, Jaggi T, et al. (2004). Overcoming barriers to adopting and implementing computerized physician order entry systems in U.S hospitals. Health Aff (Millwood).
Powsner SM, Wyatt JC, Wright P. (1998). Opportunities for and challenges of computerisation. Lancet.
Pringle M, Robins S, Brown G. (1984). Computers in the surgery. The patient's view. Br Med J (Clin Res Ed).
Pringle M, Robins S, Brown G. (1985). Topic analysis: an objective measure of the consultation and its application to computer assisted consultations. Br Med J (Clin Res Ed).
Protti D. (2002). What can the American electronic health record (EHR) pioneers tell us about what it takes to be successful?. Healthc Manage Forum.
Purves I. (1995). Computerised guidelines in primary health care: reflections and implications. Stud Health Technol Inform.
Rader RW, Toalson TW. (2001). Ready or not hand-held prescribing is coming. J Okla State Med Assoc.
Raghupathi W, Tan J. (1999). Strategic uses of information technology in health care: a state-of-the-art survey. Top Health Inf Manage.
Ralston JD, Revere D, Robins LS, et al. (2004). Patients' experience with a diabetes support programme based on an interactive electronic medical record: qualitative study. BMJ.
Ramos JD, Rai Chaudhuri A, Neill RW. (2004). International online discussion lists on chronic myelogenous leukaemia. BMJ.
Ramsaroop P, Ball MJ. (2000). The “bank of health”. A model for more useful patient health records. MD Comput.
Ramsey SD, McIntosh M, Etzioni R, et al. (2000). Simulation modeling of outcomes and cost effectiveness. Hematol Oncol Clin North Am.
Ranke MB, Dowie J. (1999). KIGS and KIMS as tools for evidence-based medicine. Horm Res.
Reed H. (1997). Streamlining patient access with a paperless system. NAHAM Manage J.
Rehm S, Kraft S. (2001). Electronic medical records: the FPM vendor survey. Fam Pract Manag.
Renner K. Electronic medical records in the outpatient setting (Part 1) . Med Group Manage J 1996;43(3)52,54,56–7 passim. [Rec#: 838]
Renner K. Electronic medical records in the outpatient setting (Part 2) . Med Group Manage J 1996;43(4):60–5, 82. [Rec#: 839]
Retchin SM, Wenzel RP. (1999). Electronic medical record systems at academic health centers: advantages and implementation issues. Acad Med.
Rettig RA. (2000). Are patients a scarce resource for academic clinical research?. Health Aff (Millwood).
Rhodes H, Dougherty M. (2003). Practice brief. Document imaging as a bridge to the EHR. J Ahima.
Ridsdale L, Hudd S. (1994). Computers in the consultation: the patient's view. Br J Gen Pract.
Robinson A, Thomson RG. (2000). The potential use of decision analysis to support shared decision making in the face of uncertainty: the example of atrial fibrillation and warfarin anticoagulation. Qual Health Care.
Robinson TN, Patrick K, Eng TR, et al. (1998). An evidence-based approach to interactive health communication: a challenge to medicine in the information age. Science Panel on Interactive Communication and Health. Jama.
Rogoski RR. The ABCs of CPRs and EMRs. Definitions semantics product differences and the need for demonstrated results hinder wide-scale adoption . Health Manag Technol 2002;23(5):14–6, 19. [Rec#: 583]
Rogoski RR. (2003). Having it your way. Three physicians who were early adopters and who remain vocal EMR advocates share their insights about the utilization challenges and benefits of EMRs. Health Manag Technol.
Rogoski RR. (2003). Opening the floodgates of usability. Clinical information systems allow free flow of patient data to clinicians when and where they need it. Health Manag Technol.
Rogoski RR. (2002). You say tomato and While the practice management landscape has blossomed with progressive technology still differences exist in issues of EMR integration and HIPAA endures as the looming challenge of the decade. Health Manag Technol.
Roland MO, Zander LI, Evans M, et al. (1985). Evaluation of a computer assisted repeat prescribing programme in a general practice. Br Med J (Clin Res Ed).
Rollman BL, Gilbert T, Lowe HJ, et al. (1999). The electronic medical record: its role in disseminating depression guidelines in primary care practice. Int J Psychiatry Med.
Roos NP, Black C, Roos LL, et al. (1998). Managing health services: how administrative data and population-based analyses can focus the agenda. Health Serv Manage Res.
Roos NP, Black C, Roos LL, et al. (1999). Managing health services: how the Population Health Information System (POPULIS) works for policymakers. Med Care.
Roper WL, Mays G. (1999). A maturing market for health information technology?. Health Aff (Millwood).
Rosenfeld S, Zeitler E, Mendelson D. Financial Incentives: Innovative Payment for Health Information Technology. 2004. [Rec#: 941]
Rosenquist PB, Colenda CC, Briggs J, et al. (1996). Riding a Trojan horse: computerized psychiatric treatment planning using managed care principles. Manag Care Q.
Rosenstein AH. (1997). Using information management to implement a clinical resource management program. Jt Comm J Qual Improv.
Rosse C. (1999). Information technology: value to patients. Health Aff (Millwood).
Rosser WW, McDowell I, Newell C. (1991). Use of reminders for preventive procedures in family medicine. CMAJ.
Ruffin M. (1996). Information Technology, Part 1: A way to streamline medical practice. Physician Exec.
Russell J, Greenhalgh T, Boynton P, et al. (2004). Soft networks for bridging the gap between research and practice: illuminative evaluation of CHAIN. BMJ.
Sackett DL, Straus SE. (1998). Finding and applying evidence during clinical rounds: the “evidence cart”. Jama.
Safran C, Rind DM, Davis RB, et al. (1996). Effects of a knowledge-based electronic patient record in adherence to practice guidelines. MD Comput.
Samsa GP, Reutter RA, Parmigiani G, et al. (1999). Performing cost-effectiveness analysis by integrating randomized trial data with a comprehensive decision model: application to treatment of acute ischemic stroke. J Clin Epidemiol.
Sanders GD, Hagerty CG, Sonnenberg FA, et al. (1999). Distributed decision support using a web-based interface: prevention of sudden cardiac death. Med Decis Making.
Sandrick K. (1998). Calculating ROI for CPRs. Health Manag Technol.
Sarasin FP. (1999). Decision analysis and the implementation of evidence-based medicine. Qjm.
Sargent JA. (2002). Identifying the value of computers in dialysis. Blood Purif.
Satava RM. (1995). Medical applications of virtual reality. J Med Syst.
Sausser GD. (2003). Thin is in: web-based systems enhance security clinical quality. Healthc Financ Manage.
Scalise D. (2002). CPOE (computerized physician order entry). An executive's guide. Hosp Health Netw.
Schadow G, Russler DC, McDonald CJ. (2001). Conceptual alignment of electronic health record data with guideline and workflow knowledge. Int J Med Inf.
Scharf L. (1997). Revising nursing documentation to meet patient outcomes. Nurs Manage.
Schiff GD, Klass D, Peterson J, et al. (2003). Linking laboratory and pharmacy: opportunities for reducing errors and improving care. Arch Intern Med.
Schiff GD, Rucker TD. (1998). Computerized prescribing: building the electronic infrastructure for better medication usage. JAMA.
Schleyer T, Spallek H. (2001). Dental informatics. A cornerstone of dental practice. J Am Dent Assoc.
Schmidt IK, Svarstad BL. (2002). Nurse-physician communication and quality of drug use in Swedish nursing homes. Soc Sci Med.
Schmitt KF, Wofford DA. (2002). Financial analysis projects clear returns from electronic medical records. Healthc Financ Manage.
Schmitz HH. (1977). A protocol for evaluating hospital information systems. Hosp Health Serv Adm.
Schneider EC, Eisenberg JM. (1998). Strategies and methods for aligning current and best medical practices. The role of information technologies. West J Med.
Schneider EC, Riehl V, Courte-Wienecke S, et al. (1999). Enhancing performance measurement: NCQA's road map for a health information framework. National Committee for Quality Assurance. JAMA.
Schneider JH. (2001). Online personal medical records: are they reliable for acute/critical care?. Crit Care Med.
Schuster DM, Hall SE, Couse CB, et al. (2003). Involving users in the implementation of an imaging order entry system. J Am Med Inform Assoc.
Sciamanna CN, Ford DE, Flynn JA, et al. (1999). An evidence-based interactive computer program to assist physicians in counseling smokers to quit. MD Comput.
Scott JS. EDI plays major role in coordinating care. Health Manag Technol 1995;16(2):36–8, 40. [Rec#: 841]
Sennett C. (1998). Moving ahead measure by measure. Health Aff (Millwood).
Seroussi B, Bouaud J, Dreau H, et al. (2001). ASTI: a guideline-based drug-ordering system for primary care. Medinfo.
Shafazand S, Shigemitsu H, Weinacker AB. (2000). A brave new world: remote intensive care unit for the 21st century. Crit Care Med.
Shaffer DW, Kigin CM, Kaput JJ, et al. (2002). What is digital medicine?. Stud Health Technol Inform.
Shaikh I. (1997). What works. New VA facility uses paperless medical records systems to compete. Health Manag Technol.
Shani M. (2000). The impact of information on medical thinking and health care policy. Int J Med Inf.
Shea S, Starren J, Weinstock RS, et al. (2002). Columbia University's Informatics for Diabetes Education and Telemedicine (IDEATel) Project: rationale and design. J Am Med Inform Assoc.
Shiffman RN, Brandt CA, Liaw Y, et al. (1999). A design model for computer-based guideline implementation based on information management services. J Am Med Inform Assoc.
Shojania KG, Duncan BW, McDonald KM. Making health care safer: a critical analysis of patient safety practices. Evid Rep Technol Assess (Summ) 2001;(43):i–x, 1–668. [Rec#: 992]
Shojania KG, Duncan BW, McDonald KM, et al. (2002). Safe but sound. Patient safety meets evidence-based medicine. JAMA.
Sicotte C, Denis JL, Lehoux P. (1998). The computer based patient record: a strategic issue in process innovation. J Med Syst.
Sim I, Gorman P, Greenes RA, et al. (2001). Clinical decision support systems for the practice of evidence-based medicine. J Am Med Inform Assoc.
Sim I, Sanders GD, McDonald KM. (2002). Evidence-based practice for mere mortals: the role of informatics and health services research. J Gen Intern Med.
Sirio CA, Segel KT, Keyser DJ, et al. (2003). Pittsburgh Regional Healthcare Initiative: a systems approach for achieving perfect patient care. Health Aff (Millwood).
Sittig DF, Stead WW. (1994). Computer-based physician order entry: the state of the art. J Am Med Inform Assoc.
Siwicki B. Outpatient electronic records. Tackling the challenges. Health Data Manag 1997;5(5):66–8, 79, 74 passim. [Rec#: 843]
Smith B. (1997). Computer-based patient records support organizational redesign. Hosp Technol Ser.
Smith D, Newell LM. (2003). Deploying the EMR: Part 2 Implementation. J Med Pract Manage.
Smith J. (2001). The case for capitalism in healthcare. Health Manag Technol.
Solomon GL, Dechter M. (1995). Are patients pleased with computer use in the examination room?. J Fam Pract.
Sonksen P, Williams C. (1996). Information technology in diabetes care ‘Diabeta’: 23 years of development and use of a computer-based record for diabetes care. Int J Biomed Comput.
Soper WD. (2002). Why I love my EMR. Fam Pract Manag.
Soto CM, Kleinman KP, Simon SR. (2002). Quality and correlates of medical record documentation in the ambulatory care setting. BMC Health Serv Res.
Staccini P, Joubert M, Quaranta JF, et al. (2001). Modelling health care processes for eliciting user requirements: a way to link a quality paradigm and clinical information system design. Int J Med Inf.
Staender S, Davies J, Helmreich B, et al. (1997). The anaesthesia critical incident reporting system: an experience based database. Int J Med Inf.
Stair TO. (1998). Reduction of redundant laboratory orders by access to computerized patient records. J Emerg Med.
Stammer L. (2001). Chart pulling brought to its knees. Healthc Inform.
Stanfill PH, Weber DG, Wayne C. (1998). Clinical patient information capture: the Columbia/HCA cancer care database experience. J Oncol Manag.
Starr P. (1997). Smart technology stunted policy: developing health information networks. Health Aff (Millwood).
Starren J, Hripcsak G, Sengupta S, et al. (2002). Columbia University's Informatics for Diabetes Education and Telemedicine (IDEATel) project: technical implementation. J Am Med Inform Assoc.
Stausberg J, Koch D, Ingenerf J, et al. (2003). Comparing paper-based with electronic patient records: lessons learned during a study on diagnosis and procedure codes. J Am Med Inform Assoc.
Stefanelli M. (2002). Knowledge management to support performance-based medicine. Methods Inf Med.
Stevens B. (1990). Development and testing of a pediatric pain management sheet. Pediatr Nurs.
Stricklin ML, Struk CM. (2003). Point of care technology: a sociotechnical approach to home health implementation. Methods Inf Med.
Struk C. (2001). Critical steps for integrating information technology in home care: one agency's experience. Home Healthc Nurse.
Sujansky WV. (1998). The benefits and challenges of an electronic medical record: much more than a “word-processed” patient chart. West J Med.
Sullivan M. The CPR's hidden impact: reducing malpractice risk. Healthc Inform 1996;13(6):36, 38, 40. [Rec#: 849]
Swanson T, Dostal J, Eichhorst B, et al. (1997). Recent implementations of electronic medical records in four family practice residency programs. Acad Med.
Sylvestri MF. Health care informatics: the key to successful disease management. Med Interface 1996;9(5):94–6, 98–9. [Rec#: 852]
Szynal D. Doctors become palm readers. Health Data Manag 2001;9(6):20, 23, 25. [Rec#: 606]
Taigman M. (2003). Ending the paper trail. Electronic documentation in EMS. Emerg Med Serv.
Takeda H, Endoh H. (2002). Commentary on ‘health care in the information society. A prognosis for the year 2013’. Int J Med Inf.
Takeda H, Matsumura Y, Nakajima K, et al. (2003). Health care quality management by means of an incident report system and an electronic patient record system. Int J Med Inf.
Tang PC. (2002). AMIA advocates national health information system in fight against national health threats. J Am Med Inform Assoc.
Tang PC, Fafchamps D, Shortliffe EH. Traditional medical records as a source of clinical data in the outpatient setting. Proc Annu Symp Comput Appl Med Care 1994;575–9. [Rec#: 125]
Tang PC, LaRosa MP, Gorden SM. (1999). Use of computer-based records, completeness of documentation, and appropriateness of documented clinical decisions. J Am Med Inform Assoc.
Tang PC, LaRosa MP, Newcomb C, et al. (1999). Measuring the effects of reminders for outpatient influenza immunizations at the point of clinical opportunity. J Am Med Inform Assoc.
Teich JM, Glaser JP, Beckley RF, et al. (1999). The Brigham integrated computing system (BICS): advanced clinical systems in an academic hospital environment. Int J Med Inf.
Teich JM, Spurr CD, Schmiz JL, et al. Enhancement of clinician workflow with computer order entry. Proc Annu Symp Comput Appl Med Care 1995;459–463. [Rec#: 40]
Teich JM, Wagner MM, Mackenzie CF, et al. (2002). The informatics response in disaster, terrorism, and war. J Am Med Inform Assoc.
Terry K. EMRs boost efficiency, too. Med Econ 2002;79(7):38–40, 43. [Rec#: 611]
Terry K. (2002). EMRS cost too much? This group says no way!. Med Econ.
Terry K. (2003). EMRs. What you need to know. Med Econ.
Terry K. How connectivity is changing practice. Med Econ 2000;77(13):166–70, 173. [Rec#: 609]
Terry K. (2003). The move to put office orders online. Med Econ.
Terry K. Will the Internet finally put an end to paperwork? Med Econ 2000;77(13):152–4, 159–60, 163–5. [Rec#: 610]
Terry NP. (2001). An eHealth diptych: the impact of privacy regulation on medical error and malpractice litigation. Am J Law Med.
Thompson C, McCaughan D, Cullum N, et al. (2001). Research information in nurses' clinical decision-making: what is useful?. J Adv Nurs.
Thomson R, Robinson A, Greenaway J, et al. (2002). Development and description of a decision analysis based decision support tool for stroke prevention in atrial fibrillation. Qual Saf Health Care.
Tierney WM. (1996). Feedback of performance and diagnostic testing: lessons from Maastricht. Med Decis Making.
Tierney WM. (2001). Improving clinical decisions and outcomes with information: a review. Int J Med Inf.
Tierney WM, Murray MD, Gaskins DL, et al. (1997). Using computer-based medical records to predict mortality risk for inner-city patients with reactive airways disease. J Am Med Inform Assoc.
Tierney WM, Overhage JM, McDonald CJ. (1997). Demonstrating the effects of an IAIMS on health care quality and cost. J Am Med Inform Assoc.
Tierney WM, Overhage JM, Takesue BY, et al. (1995). Computerizing guidelines to improve care and patient outcomes: the example of heart failure. J Am Med Inform Assoc.
Tierney WM, Takesue BY, Vargo DL, et al. (1996). Using electronic medical records to predict mortality in primary care patients with heart disease: prognostic power and pathophysiologic implications. J Gen Intern Med.
Timmermans DR, Sprij AJ, de Bel CE. (1996). The discrepancy between daily practice and the policy of a decision-analytic model: the management of fever of unknown origin. Med Decis Making.
Tomasulo P. (2003). PD(X)MD: a new clinical information tool for patient care. Med Ref Serv Q.
Tomes JP. (1996). Legal issues in the acquisition of computerized medical records and payment systems. J Health Care Finance.
Tsui FC, Espino JU, Dato VM, et al. (2003). Technical description of RODS: a real-time public health surveillance system. J Am Med Inform Assoc.
Tully M. (2000). The impact of information technology on the performance of clinical pharmacy services. J Clin Pharm Ther.
Urden LD. (1996). Development of a nurse executive decision support database. A model for outcomes evaluation. J Nurs Adm.
Utz SW. (1998). Computerized documentation of case management. From diagnosis to outcomes. Nurs Case Manag.
Valenta AL, Wigger U. Early results of user profiles: physicians' opinions on the use of information technology. Proc AMIA Annu Fall Symp 1996;65–9. [Rec#: 914]
van Ginneken AM. (2002). The computerized patient record: balancing effort and benefit. Int J Med Inf.
van Ginneken AM, Stam H, van Mulligen EM, et al. (1999). ORCA: the versatile CPR. Methods Inf Med.
Vissers MC, Greve JW, Gouma DJ, et al. (1997). Introduction of a computerised protocol in clinical practice: is there anything to gain?. Eur J Surg.
von Grey M. (2000). Focus on voice recognition. Technology moves into the mainstream. Health Manag Technol.
Wagner EH. (2000). The role of patient care teams in chronic disease management. BMJ.
Wagner EH, Austin BT, Von Korff M. (1996). Organizing care for patients with chronic illness. Milbank Q.
Walker LM. At Kaiser, a vision of the connected future. Med Econ 2002;79(3):52–4, 58. [Rec#: 623]
Walsh SH. (2004). The clinician's perspective on electronic health records and how they can affect patient care. BMJ.
Wang YZ, Wang S. (1999). Automation of clinical and patient records. South Med J.
Wanlass RL, Reutter SL, Kline AE. (1992). Communication among rehabilitation staff: “mild,” “moderate,” or “severe” deficits?. Arch Phys Med Rehabil.
Ward MD. (2001). e-Medx, Inc.'s e-POC for cancer. Case Manager.
Ward MD. (2002). InformaCare disease management system. Case Manager.
Ward SR. (2003). Health smart cards: merging technology and medical information. Med Ref Serv Q.
Waring N. (2000). To what extent are practices ‘paperless’ and what are the constraints to them becoming more so?. Br J Gen Pract.
Warren JR, Posey B, Thornton T, et al. Can computer autoacquisition of medical information meet the needs of the future? A feasibility study in direct computation of the fine grained electronic medical record. Proc AMIA Symp 1999;445–9. [Rec#: 627]
Watlington AG. Realizing system benefits: one planned step at a time. Comput Healthc 1989;10(2):32–4, 36. [Rec#: 50]
Watson S. (1996). Electronic records pay off twice. Health Data Manag.
Weaver FM, Hatzakis M, Evans CT, et al. (2004). A comparison of multiple data sources to identify vaccinations for veterans with spinal cord injuries and disorders. J Am Med Inform Assoc.
Weekley JS, Smith BJ, Pradhan M. (2000). The intersection of health informatics and evidence-based medicine: computer-based systems to assist clinicians. Med J Aust.
Weiner M, Callahan CM, Tierney WM, et al. (2003). Using information technology to improve the health care of older adults. Ann Intern Med.
Weingarten M, Andrew WF. The CPR: balancing quality and cost. Healthc Inform 1996;13(8):44, 46, 48. [Rec#: 858]
Weingarten SR, Henning JM, Badamgarav E, et al. (2002). Interventions used in disease management programmes for patients with chronic illness-which ones work? Meta-analysis of published reports. BMJ.
Weinstein MC, O'Brien B, Hornberger J, et al. (2003). Principles of good practice for decision analytic modeling in health-care evaluation: report of the ISPOR Task Force on Good Research Practices--Modeling Studies. Value Health.
Welton JM, Jarr S. (1997). Automating and improving the data quality of a nursing department quality management program at a university hospital. Jt Comm J Qual Improv.
Westra B, Raup G. (1995). Computerized charting--an essential tool for survival. Caring.
Whitlock WL, Brown A, Moore K, et al. (2000). Telemedicine improved diabetic management. Mil Med.
Willey CJ, Struckhoff B. Physicians use EMR to improve quality. Esse Health takes lead in primary care technology, quality. Med Group Manage J 1999;46(6):18–21, 24–7. [Rec#: 629]
Williams B. (2001). The untapped potential of electronic medical records. Pt. 1--Road-testing the promises of EMR technology. Tenn Med.
Williams B. (2001). The untapped potential of electronic medical records. Pt. 2--Solving the problems of EMR technology. Tenn Med.
Williams C, Whitfield G. (2001). Written and computer-based self-help treatments for depression. Br Med Bull.
Wong BK, Sellaro CL, Monaco JA. (1995). Information systems analysis approach in hospitals: a national survey. Health Care Superv.
Wong ET, Abendroth TW. Reaping the benefits of medical information systems. Acad Med 1996;71(4):353–7. [Rec#: 409]
Wood L, Coulson R. (2001). Revitalizing the General Practice Research Database: plans, challenges, and opportunities. Pharmacoepidemiol Drug Saf.
Worth ER, Patrick TB. Do electronic mail discussion lists act as virtual colleagues? Proc AMIA Annu Fall Symp 1997;325–9. [Rec#: 139]
Wu AW, Pronovost P, Morlock L. (2002). ICU incident reporting systems. J Crit Care.
Wu R, Peters W, Morgan MW. (2002). The next generation of clinical decision support: linking evidence to best practice. J Healthc Inf Manag.
Wulff HR. (2000). Clinical medicine in the age of the computer. Aust N Z J Med.
Young AS, Mintz J, Cohen AN, et al. (2004). A Network-Based System to Improve Care for Schizophrenia: The Medical Informatics Network Tool (MINT). J Am Med Inform Assoc.
Zielstorff RD, Barnett GO, Fitzmaurice JB, et al. A decision support system for prevention and treatment of pressure ulcers based on AHCPR guidelines. Proc AMIA Annu Fall Symp 1996;562–6. [Rec#: 722]
Zoccali C. (2001). The importance of large, high quality clinical databases in nephrology. J Nephrol.
Zurhellen W. (2001). The coming of age of the electronic office. Pediatr Ann.
Zvarova J, Tomeckova M, Stefek M, et al. (1997). Decision support and data analysis tools for risk assessment in primary preventive study of atherosclerosis. Stud Health Technol Inform.