# Appendix F: Articles Included in HIT Interactive Database

Abookire SA, Teich JM, Sandige H, et al. Improving allergy alerting in a computerized physician order entry system. Proc AMIA Symp 2000;2–6. [Rec#: 54]
Agrawal A. (2002). Return on investment analysis for a computer-based patient record in the outpatient clinic setting. J Assoc Acad Minor Phys.
Al-Aynati MM, Chorneyko KA. (2003). Comparison of voice-automated transcription and human transcription in generating pathology reports. Arch Pathol Lab Med.
Alvis JM, Reves JG, Govier AV, et al. (1985). Computer-assisted continuous infusions of fentanyl during cardiac anesthesia: comparison with a manual method. Anesthesiology.
Ammenwerth E, Eichstadter R, Haux R, et al. (2001). A randomized evaluation of a computer-based nursing documentation system. Methods Inf Med.
Ammenwerth E, Mansmann U, Iller C, et al. (2003). Factors affecting and affected by user acceptance of computer-based nursing documentation: results of a two-year study. J Am Med Inform Assoc.
Anderson JG, Jay SJ, Anderson M, et al. (2002). Evaluating the capability of information technology to prevent adverse drug events: A computer simulation approach. J Am Med Inform Assoc.
Arias-Vimarlund V, Ljunggren M, Timpka T. Implementation of computer-based patient records in primary care: the societal health economic effects. Proc AMIA Annu Fall Symp 1996;503–7. [Rec#: 182]
Baird TK, Broekemeier RL, Anderson MW. (1984). Effectiveness of a computer-supported refill reminder system. Am J Hosp Pharm.
Balas EA, Austin SM, Mitchell JA, et al. (1996). The clinical value of computerized information services. A review of 98 randomized clinical trials. Arch Fam Med.
Balas EA, Boren SA, Griffing G . Computerized management of diabetes: a synthesis of controlled trials. Proc AMIA Symp 1998;295–9. [Rec#: 185]
Balas EA, Jaffrey F, Kuperman GJ, et al. (1997). Electronic communication with patients. Evaluation of distance medicine technology. JAMA.
Balas EA, Weingarten S, Garb CT, et al. (2000). Improving preventive care by prompting physicians. Arch Intern Med.
Baldwin DR, Beech CA, Evans AH, et al. (1997). Principals of design and evaluation of an information system for a department of respiratory medicine. Health Care Anal.
Ball A, Goodman M, Evans L, et al. (1999). Computer generated discharge summaries and their use as a case mix sensitive audit engine. A tale of two cities. J R Coll Physicians Lond.
Barton MB, Schoenbaum SC. (1990). Improving influenza vaccination performance in an HMO setting: the use of computer-generated reminders and peer comparison feedback. Am J Public Health.
Bass DM, McClendon MJ, Brennan PF, et al. (1998). The buffering effect of a computer support network on caregiver strain. J Aging Health.
Bates DW, Boyle DL, Teich JM. Impact of computerized physician order entry on physician time. Proc Annu Symp Comput Appl Med Care 1994;996.[Rec#: 2]
Bates DW, Kuperman GJ, Rittenberg E, et al. (1999). A randomized trial of a computer-based intervention to reduce utilization of redundant laboratory tests. Am J Med.
Bates DW, Leape LL, Cullen DJ, et al. (1998). Effect of computerized physician order entry and a team intervention on prevention of serious medication errors. JAMA.
Bates DW, Teich JM, Lee J, et al. (1999). The impact of computerized physician order entry on medication error prevention. J Am Med Inform Assoc.
Becker DM, Gomez EB, Kaiser DL, et al. (1989). Improving preventive care at a medical clinic: how can the patient help. Am J Prev Med.
Becker SH, Arenson RL. (1994). Costs and benefits of picture archiving and communication systems. J Am Med Inform Assoc.
Bennett JW, Glasziou PP. (2003). Computerised reminders and feedback in medication management: a systematic review of randomised controlled trials. Med J Aust.
Bessell TL, McDonald S, Silagy CA, et al. (2002). Do Internet interventions for consumers cause more harm than good? A systematic review. Health Expect.
Boldreghini S, Larrabee JH. Difference in nursing documentation before and after computerization: A pilot study. J Nurs Inform [serial online] 1998;2(1).[Rec#: 988]
Bouhaddou O, Lambert JG, Morgan GE. Iliad and Medical HouseCall: evaluating the impact of common sense knowledge on the diagnostic accuracy of a medical expert system. Proc Annu Symp Comput Appl Med Care 1995;742–6. [Rec#: 725]
Brettle A. (2003). Information skills training: a systematic review of the literature. Health Info Libr J.
Brownbridge G, Evans A, Fitter M, et al. (1986). An interactive computerized protocol for the management of hypertension: effects on the general practitioner's clinical behaviour. J R Coll Gen Pract.
Brownbridge G, Evans A, Wall T. (1985). Effect of computer use in the consultation on the delivery of care. Br Med J (Clin Res Ed).
Bulpitt CJ, Beilin LJ, Coles EC, et al. (1976). Randomised controlled trial of computer-held medical records in hypertensive patients. Br Med J.
Burack RC, Gimotty PA. (1997). Promoting screening mammography in inner-city settings. The sustained effectiveness of computerized reminders in a randomized controlled trial. Med Care.
Burack RC, Gimotty PA, George J, et al. (1994). Promoting screening mammography in inner-city settings: a randomized controlled trial of computerized reminders as a component of a program to facilitate mammography. Med Care.
Burkle T, Kuch R, Prokosch HU, et al. (1999). Stepwise evaluation of information systems in an university hospital. Methods Inf Med.
Burkle T, Michel A, Horch W, et al. (1998). Computer based nursing documentation means to achieve the goal. Int J Med Inf.
Burton ME, Ash CL, Hill DP=, et al. (1991). A controlled trial of the cost benefit of computerized bayesian aminoglycoside administration. Clin Pharmacol Ther.
Bushko RG, Havlicek PL, Deppert E, et al. (2002). Impact of voice- and knowledge-enabled clinical reporting--US example. Stud Health Technol Inform.
Cameron S, Regalado M, Quitoles M, et al. (1999). Harnessing technology: the creation of an electronic care management record in a social health maintenance organization. Manag Care Q.
Campbell SM, Roland MO, Gormanly B. (1996). Evaluation of a computerized appointment system in general practice. Br J Gen Pract.
Cannon DS, Allen SN. (2000). A comparison of the effects of computer and manual reminders on compliance with a mental health clinical practice guideline. J Am Med Inform Assoc.
Car J, Sheikh A. (2004). Email consultations in health care: 1--scope and effectiveness. BMJ.
Carmenates J, Keith MR. (2001). Impact of automation on pharmacist interventions and medication errors in a correctional health care system. Am J Health Syst Pharm.
Carroll AE, Tarczy-Hornoch P, O'Reilly E, et al. (2004). The effect of point-of-care personal digital assistant use on resident documentation discrepancies. Pediatrics.
Carroll AE, Tarczy-Hornoch P, O'Reilly E, et al. (2004). The effect of point-of-care personal digital assistant use on resident documentation discrepancies. Pediatrics.
Casner PR, Reilly R, Ho H. (1993). A randomized controlled trial of computerized pharmacokinetic theophylline dosing versus empiric physician dosing. Clin Pharmacol Ther.
Chambers CV, Balaban DJ, Carlson BL, et al. (1991). The effect of microcomputer-generated reminders on influenza vaccination rates in a university-based family practice center. J Am Board Fam Pract.
Chambers CV, Balaban DJ, Carlson BL, et al. (1989). Microcomputer-generated reminders. Improving the compliance of primary care physicians with mammography screening guidelines. J Fam Pract.
Chatellier G, Colombet I, Degoulet P. (1998). Computer-adjusted dosage of anticoagulant therapy improves the quality of anticoagulation. Medinfo.
Chatellier G, Colombet I, Degoulet P. (1998). An overview of the effect of computer-assisted management of anticoagulant therapy on the quality of anticoagulation. Int J Med Inf.
Chen P, Tanasijevic MJ, Schoenenberger RA, et al. (2003). A computer-based intervention for improving the appropriateness of antiepileptic drug level monitoring. Am J Clin Pathol.
Chertow GM, Lee J, Kuperman GJ, et al. (2001). Guided medication dosing for inpatients with renal insufficiency. JAMA.
ChiarelliM F, Tumini S, Morgese G, et al. (1990). Controlled study in diabetic children comparing insulin-dosage adjustment by manual and computer algorithms. Diabetes Care.
Chin HL, Wallace P. Embedding guidelines into direct physician order entry: simple methods, powerful results. Proc AMIA Symp 1999;221–5. [Rec#: 465]
Chin JM, Muller RJ, Lucarelli CD. A pharmacy intervention program: recognizing pharmacy's contribution to improving patient care. Hosp Pharm 1995;30(2):120, 123–6, 129–30. [Rec#: 206]
Christakis DA, Zimmerman FJ, Wright JA, et al. (2001). A randomized controlled trial of point-of-care evidence to improve the antibiotic prescribing practices for otitis media in children. Pediatrics.
Christensen-Szalanski JJ, Diehr PH, Wood RW, et al. (1982). Phased trial of a proven algorithm at a new primary care clinic. Am J Public Health.
Classen DC, Pestotnik SL, Evans RS, et al. (1997). Adverse drug events in hospitalized patients. Excess length of stay, extra costs, and attributable mortality. JAMA.
Coe FL, Norton E, Oparil S, et al. (1977). Treatment of hypertension by computer and physician-a prospective controlled study. J Chronic Dis.
Cordero L, Kuehn L, Kumar RR, et al. (2004). Impact of computerized physician order entry on clinical practice in a newborn intensive care unit. J Perinatol.
Daly JM, Buckwalter K, Maas M. (2002). Written and computerized care plans. Organizational processes and effect on patient outcomes. J Gerontol Nurs.
Davidson KW, Kahn A, Price RD. (1987). Reduction of adverse drug reactions by computerized drug interaction screening. J Fam Pract.
Day F, Hoang LP, Ouk S, et al. The impact of a guideline-driven computer charting system on the emergency care of patients with acute low back pain. Proc Annu Symp Comput Appl Med Care 1995;576–80. [Rec#: 724]
Demakis JG, Beauchamp C, Cull WL, et al. (2000). Improving residents' compliance with standards of ambulatory care: results from the VA Cooperative Study on Computerized Reminders. JAMA.
Dexter PR, Perkins SM, Maharry KS, et al. (2004). Inpatient Computer-based Standing Orders vs physician reminders to increase influenza and pneumococcal vaccination rates. JAMA.
Dexter PR, Wolinsky FD, Gramelspacher GP, et al. (1998). Effectiveness of computer-generated reminders for increasing discussions about advance directives and completion of advance directive forms. A randomized, controlled trial. Ann Intern Med.
Dickinson JC, Warshaw GA, Gehlbach SH, et al. (1981). Improving hypertension control: impact of computer feedback and physician education. Med Care.
Donald JB. (1989). Prescribing costs when computers are used to issue all prescriptions. BMJ.
Durieux P, Nizard R, Ravaud P, et al. (2000). A clinical decision support system for prevention of venous thromboembolism: effect on physician behavior. JAMA.
Eadie LH, Seifalian AM, Davidson BR. (2003). Telemedicine in surgery. Br J Surg.
Eccles M, McColl E, Steen N, et al. (2002). Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ.
Ehler D, Vacek JL, Bansal S, et al. (2000). Transition to an all digital echocardiography laboratory: a large, multi-site private cardiology practice experience. J Am Soc Echocardiogr.
Evans RS, Classen DC, Pestotnik SL, et al. (1994). Improving empiric antibiotic selection using computer decision support. Arch Intern Med.
Evans RS, Classen DC, Stevens LE, et al. Using a hospital information system to assess the effects of adverse drug events. Proc Annu Symp Comput Appl Med Care 1993;161–165. [Rec#: 17]
Evans RS, Larsen RA, Burke JP, et al. (1986). Computer surveillance of hospital-acquired infections and antibiotic use. JAMA.
Evans RS, Pestotnik SL, Classen DC, et al. Prevention of adverse drug events through computerized surveillance. Proc Annu Symp Comput Appl Med Care 1992;437–441. [Rec#: 18]
Evans RS, Pestotnik SL, Classen DC, et al. (1999). Evaluation of a computer-assisted antibiotic-dose monitor. Ann Pharmacother.
Evans RS, Pestotnik SL, Classen DC, et al. (1998). A computer-assisted management program for antibiotics and other antiinfective agents. N Engl J Med.
Eysenbach G, Powell J, Englesakis M, et al. (2004). Health related virtual communities and electronic support groups: systematic review of the effects of online peer to peer interactions. BMJ.
Fihn SD, McDonell MB, Vermes D, et al. (1994). A computerized intervention to improve timing of outpatient follow up: a multicenter randomized trial in patients treated with warfarin. National Consortium of Anticoagulation Clinics. J Gen Intern Med.
Fitzmaurice DA, Hobbs FD, Delaney BC, et al. (1998). Review of computerized decision support systems for oral anticoagulation management. Br J Haematol.
Fitzmaurice DA, Hobbs FD, Murray ET, et al. (1996). Evaluation of computerized decision support for oral anticoagulation management based in primary care. Br J Gen Pract.
Fortescue EB, Kaushal R, Landrigan CP, et al. (2003). Prioritizing strategies for preventing medication errors and adverse drug events in pediatric inpatients. Pediatrics.
Frame PS, Zimmer JG, Werth PL, et al. (1994). Computer-based vs manual health maintenance tracking. A controlled trial. Arch Fam Med.
Frances CD, Alperin P, Adler JS, et al. (2001). Does a fixed physician reminder system improve the care of patients with coronary artery disease? A randomized controlled trial. West J Med.
Friedman CP, Elstein AS, Wolf FM, et al. (1999). Enhancement of clinicians' diagnostic reasoning by computer-based consultation: a multisite study of 2 systems. JAMA.
Gajewski LK, Vanscoy GJ, Dean JC, et al. The development of a computerized LAN-based investigational drug information database. Hosp Pharm 1995;30(12):1113, 1116–8, 1120. [Rec#: 240]
Gamm LD, Barsukiewicz CK, Dansky KH, et al. (1998). Investigating changes in end-user satisfaction with installation of an electronic medical record in ambulatory care settings. J Healthc Inf Manag.
Garg AX, Adhikari NK, McDonald H, et al. (2005). Effects of computerized clinical decision support systems on practitioner performance and patient outcomes: a systematic review. JAMA.
Garr DR, Ornstein SM, Jenkins RG, et al. (1993). The effect of routine use of computer-generated preventive reminders in a clinical practice. Am J Prev Med.
Garrido T, Jamieson L, Zhou Y, et al. (2005). Effect of electronic health records in ambulatory care: retrospective, serial, cross sectional study. BMJ.
Gehlbach SH, Wilkinson WE, Hammond WE, et al. (1984). Improving drug prescribing in a primary care practice. Med Care.
Gilliland A, Mills KA, Steele K. (1992). General practitioner records on computer--handle with care. Fam Pract.
Gioia PC. Quality improvement in pediatric well care with an electronic record. Proc AMIA Symp 2001;209–13. [Rec#: 493]
Goethe JW, Schwartz HI, Szarek BL. (1997). Physician compliance with practice guidelines. Conn Med.
Goldman L, Cook EF, Brand DA, et al. (1988). A computer protocol to predict myocardial infarction in emergency department patients with chest pain. N Engl J Med.
Gonzalez ER, Vanderheyden BA, Ornato JP, et al. (1989). Computer-assisted optimization of aminophylline therapy in the emergency department. Am J Emerg Med.
Gray J, Majeed A, Kerry S, et al. (2000). Identifying patients with ischaemic heart disease in general practice: cross sectional study of paper and computerised medical records. Bmj.
Greist JH, Marks IM, Baer L, et al. (2002). Behavior therapy for obsessive-compulsive disorder guided by a computer or by a clinician compared with relaxation as a control. J Clin Psychiatry.
Harris RP, O'Malley MS, Fletcher SW, et al. (1990). Prompting physicians for preventive procedures: a five-year study of manual and computer reminders. Am J Prev Med.
Heden B, Ohlin H, Rittner R, et al. (1997). Acute myocardial infarction detected in the 12-lead ECG by artificial neural networks. Circulation.
Hersh WR, Hickam DH. (1998). How well do physicians use electronic information retrieval systems? A framework for investigation and systematic review. Jama.
Hershey CO, Porter DK, Breslau D, et al. (1986). Influence of simple computerized feedback on prescription charges in an ambulatory clinic. A randomized clinical trial. Med Care.
Herzmark G, Brownbridge G, Fitter M, et al. (1984). Consultation use of a computer by general practitioners. J R Coll Gen Pract.
Hetlevik I, Holmen J, Kruger O. (1999). Implementing clinical guidelines in the treatment of hypertension in general practice. Evaluation of patient outcome related to implementation of a computer-based clinical decision support system. Scand J Prim Health Care.
Hickling K, Begg E, Moore ML. (1989). A prospective randomised trial comparing individualised pharmacokinetic dosage prediction for aminoglycosides with prediction based on estimated creatinine clearance in critically ill patients. Intensive Care Med.
Hobbs FD, Delaney BC, Carson A, et al. (1996). A prospective controlled trial of computerized decision support for lipid management in primary care. Fam Pract.
Honigman B, Lee J, Rothschild J, et al. (2001). Using computerized data to identify adverse drug events in outpatients. J Am Med Inform Assoc.
Hooker RC, Cowap N, Newson R, et al. (1999). Better by half: hypertension in the elderly and the ‘rule of halves’: a primary care audit of the clinical computer record as a springboard to improving care. Fam Pract.
Hutchison BG. (1989). Effect of computer-generated nurse/physician reminders on influenza immunization among seniors. Fam Med.
Jha AK, Kuperman GJ, Teich JM, et al. (1998). Identifying adverse drug events: development of a computer-based monitor and comparison with chart review and stimulated voluntary report. J Am Med Inform Assoc.
Johnson KB, Davison CL. (2004). Information technology: its importance to child safety. Ambul Pediatr.
Johnston B, Wheeler L, Deuser J, et al. (2000). Outcomes of the Kaiser Permanente Tele-Home Health Research Project. Arch Fam Med.
Jones DL, Kroenke K, Landry FJ, et al. (1996). Cost savings using a stepped-care prescribing protocol for nonsteroidal anti-inflammatory drugs. JAMA.
Kaltenthaler E, Shackley P, Stevens K, et al. (2002). A systematic review and economic evaluation of computerised cognitive behaviour therapy for depression and anxiety. Health Technol Assess.
Kaushal R, Shojania KG, Bates DW. (2003). Effects of computerized physician order entry and clinical decision support systems on medication safety: a systematic review. Arch Intern Med.
Kenkre J, Drury VW, Lancashire RJ. (1985). Nurse management of hypertension clinics in general practice assisted by a computer. Fam Pract.
Kerr EA, Smith DM, Hogan MM, et al. (2002). Comparing clinical automated, medical record, and hybrid data sources for diabetes quality measures. Jt Comm J Qual Improv.
Khoury A. (1997). Finding value in EMRs (electronic medical records). Health Manag Technol.
Kian LA, Stewart MW, Bagby C, et al. Justifying the cost of a computer-based patient record. Healthc Financ Manage 1995;49(7):58–60, 62, 64–7. [Rec#: 802]
Kilgore ML, Flint D, Pearce R. (1998). The varying impact of two clinical information systems in a cardiovascular intensive care unit. J Cardiovasc Manag.
King WJ, Paice N, Rangrej J, et al. (2003). The effect of computerized physician order entry on medication errors and adverse drug events in pediatric inpatients. Pediatrics.
Kovner C, Schuchman L, Mallard C. (1997). The application of pen-based computer technology to home health care. Comput Nurs.
Krall MA. Acceptance and performance by clinicians using an ambulatory electronic medical record in an HMO. Proc Annu Symp Comput Appl Med Care 1995;708–11. [Rec#: 804]
Kramer TL, Owen RR, Cannon D, et al. (2003). How well do automated performance measures assess guideline implementation for new-onset depression in the Veterans Health Administration?. Jt Comm J Qual Saf.
Krishna S, Balas EA, Spencer DC, et al. (1997). Clinical trials of interactive computerized patient education: implications for family practice. J Fam Pract.
Kucher N, Koo S, Quiroz R, et al. (2005). Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med.
Kuperman GJ , Teich JM, Bates DW, et al. Detecting alerts, notifying the physician, and offering action items: a comprehensive alerting system. Proc AMIA Annu Fall Symp 1996;704–708. [Rec#: 25]
Kuperman GJ, Teich JM, Tanasijevic MJ, et al. (1999). Improving response to critical laboratory results with automation: results of a randomized controlled trial. J Am Med Inform Assoc.
Larrabee JH, Boldreghini S, Elder-Sorrells K, et al. Evaluation of documentation before and after implementation of a nursing information system in an acute care hospital. Comput Nurs 2001;19(2):56–65; quiz 66–8. [Rec#: 670]
Larsen RA, Evans RS, Burke JP, et al. (1989). Improved perioperative antibiotic use and reduced surgical wound infections through use of computer decision analysis. Infect Control Hosp Epidemiol.
Lewis G, Sharp D, Bartholomew J, et al. (1996). Computerized assessment of common mental disorders in primary care: effect on clinical outcome. Fam Pract.
Liaw T, Lawrence M, Rendell J. (1996). The effect of a computer-generated patient-held medical record summary and/or a written personal health record on patients' attitudes, knowledge and behaviour concerning health promotion. Fam Pract.
Lisboa PJ. (2002). A review of evidence of health benefit from artificial neural networks in medical intervention. Neural Netw.
Litzelman DK, Dittus RS, Miller ME, et al. (1993). Requiring physicians to respond to computerized reminders improves their compliance with preventive care protocols. J Gen Intern Med.
Lobach DF. Electronically distributed, computer-generated, individualized feedback enhances the use of a computerized practice guideline. Proc AMIA Annu Fall Symp 1996;493–7. [Rec#: 894]
Lobach DF, Hammond WE. (1997). Computerized decision support based on a clinical practice guideline improves compliance with care standards. Am J Med.
Lobach DF, Hammond WE. Development and evaluation of a Computer-Assisted Management Protocol (CAMP): improved compliance with care guidelines for diabetes mellitus. Proc Annu Symp Comput Appl Med Care 1994;787–91. [Rec#: 895]
Margolis CZ, Warshawsky SS, Goldman L, et al. (1992). Computerized algorithms and pediatricians' management of common problems in a community clinic. Acad Med.
Marr PB, Duthie E, Glassman KS, et al. (1993). Bedside terminals and quality of nursing documentation. Comput Nurs.
Mc Donald CJ. (1976). Use of a computer to detect and respond to clinical events: its effect on clinician behavior. Ann Intern Med.
McAlister NH, Covvey HD, Tong C, et al. (1986). Randomised controlled trial of computer assisted management of hypertension in primary care. Br Med J (Clin Res Ed).
McCartney P, Macdowall W, Thorogood M. (1997). A randomised controlled trial of feedback to general practitioners of their prophylactic aspirin prescribing. BMJ.
McCowan C, Neville RG, Ricketts IW, et al. (2001). Lessons from a randomized controlled trial designed to evaluate computer decision support software to improve the management of asthma. Med Inform Internet Med.
McDonald CJ. (1976). Protocol-based computer reminders, the quality of care and the non-perfectability of man. N Engl J Med.
McDonald CJ, Hui SL, Smith DM, et al. (1984). Reminders to physicians from an introspective computer medical record. A two-year randomized trial. Ann Intern Med.
McDonald CJ, Hui SL, Tierney WM. (1992). Effects of computer reminders for influenza vaccination on morbidity during influenza epidemics. MD Comput.
McDonald CJ, Wilson GA, McCabe GP. (1980). Physician response to computer reminders. JAMA.
McDowell I, Newell C, Rosser W. (1986). Comparison of three methods of recalling patients for influenza vaccination. CMAJ.
McDowell I, Newell C, Rosser W. (1989). Computerized reminders to encourage cervical screening in family practice. J Fam Pract.
McDowell I, Newell C, Rosser W. (1990). A follow-up study of patients advised to obtain influenza immunizations. Fam Med.
McDowell I, Newell C, Rosser W. (1989). A randomized trial of computerized reminders for blood pressure screening in primary care. Med Care.
McMichael J, Lieberman R, Doyle H, et al. (1993). An intelligent and cost-effective computer dosing system for individualizing FK506 therapy in transplantation and autoimmune disorders. J Clin Pharmacol.
McNeely MD. (2002). The use of expert systems for improving test use and enhancing the accuracy of diagnosis. Clin Lab Med.
McPhee SJ, Bird JA, Fordham D, et al. (1991). Promoting cancer prevention activities by primary care physicians. Results of a randomized, controlled trial. JAMA.
Mekhjian HS, Kumar RR, Kuehn L, et al. (2002). Immediate benefits realized following implementation of physician order entry at an academic medical center. J Am Med Inform Assoc.
Mitchell E, Sullivan F. (2001). A descriptive feast but an evaluative famine: systematic review of published articles on primary care computing during 1980-97. Bmj.
Montani S, Bellazzi R, Quaglini S, et al. (2001). Meta-analysis of the effect of the use of computer-based systems on the metabolic control of patients with diabetes mellitus. Diabetes Technol Ther.
Montgomery AA, Fahey T. (1998). A systematic review of the use of computers in the management of hypertension. J Epidemiol Community Health.
Montgomery AA, Fahey T, Peters TJ, et al. (2000). Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ.
Moran WP, Nelson K, Wofford JL, et al. (1992). Computer-generated mailed reminders for influenza immunization: a clinical trial. J Gen Intern Med.
Mullett CJ, Evans RS, Christenson JC, et al. (2001). Development and impact of a computerized pediatric antiinfective decision support program. Pediatrics.
Mungall DR, Anbe D, Forrester PL, et al. (1994). A prospective randomized comparison of the accuracy of computer-assisted versus GUSTO nomogram--directed heparin therapy. Clin Pharmacol Ther.
Murchie CJ, Kenny GN. (1989). Comparison among manual, computer-assisted, and closed-loop control of blood pressure after cardiac surgery. J Cardiothorac Anesth.
Murff HJ, Kannry J. (2001). Physician satisfaction with two order entry systems. J Am Med Inform Assoc.
Nahm R, Poston I. (2000). Measurement of the effects of an integrated, point-of-care computer system on quality of nursing documentation and patient satisfaction. Comput Nurs.
Nightingale PG, Adu D, Richards NT, et al. (2000). Implementation of rules based computerised bedside prescribing and administration: intervention study. BMJ.
Nilasena DS, Lincoln MJ. A computer-generated reminder system improves physician compliance with diabetes preventive care guidelines. Proc Annu Symp Comput Appl Med Care 1995;640–5. [Rec#: 712]
Nilasena DS, Lincoln MJ, Turner CW, et al. Development and implementation of a computer-generated reminder system for diabetes preventive care. Proc Annu Symp Comput Appl Med Care 1994;831–5. [Rec#: 711]
Oren E, Shaffer ER, Guglielmo BJ. (2003). Impact of emerging technologies on medication errors and adverse drug events. Am J Health Syst Pharm.
Ornstein SM, Garr DR, Jenkins RG, et al. (1995). Implementation and evaluation of a computer-based preventive services system. Fam Med.
Ornstein SM, Garr DR, Jenkins RG, et al. (1991). Computer-generated physician and patient reminders. Tools to improve population adherence to selected preventive services. J Fam Pract.
Ornstein SM, MacFarlane LL, Jenkins RG, et al. (1999). Medication cost information in a computer-based patient record system. Impact on prescribing in a family medicine clinical practice. Arch Fam Med.
Overhage JM, Perkins S, Tierney WM, et al. (2001). Controlled trial of direct physician order entry: effects on physicians' time utilization in ambulatory primary care internal medicine practices. J Am Med Inform Assoc.
Overhage JM, Suico J, McDonald CJ. (2001). Electronic laboratory reporting: barriers, solutions and findings. J Public Health Manag Pract.
Overhage JM, Tierney WM, McDonald CJ. (1996). Computer reminders to implement preventive care guidelines for hospitalized patients. Arch Intern Med.
Overhage JM, Tierney WM, Zhou XH, et al. (1997). A randomized trial of “corollary orders” to prevent errors of omission. J Am Med Inform Assoc.
Pacht ER, Turner JW, Gailiun M, et al. (1998). Effectiveness of telemedicine in the outpatient pulmonary clinic. Telemed J.
Perlini S, Piepoli M, Marti G, et al. (1990). Treatment of chronic heart failure: an expert system advisor for general practitioners. Acta Cardiol.
Persson M, Mjorndal T, Carlberg B, et al. (2000). Evaluation of a computer-based decision support system for treatment of hypertension with drugs: retrospective, nonintervention testing of cost and guideline adherence. J Intern Med.
Peterson CM, Jovanovic L, Chanoch LH. (1986). Randomized trial of computer-assisted insulin delivery in patients with type I diabetes beginning pump therapy. Am J Med.
Pierpont GL, Thilgen D. (1995). Effect of computerized charting on nursing activity in intensive care. Crit Care Med.
Pizziferri L, Kittler AF, Volk LA, et al. (2005). Primary care physician time utilization before and after implementation of an electronic health record: a time-motion study. J Biomed Inform.
Poller L, Wright D, Rowlands M. (1993). Prospective comparative study of computer programs used for management of warfarin. J Clin Pathol.
Potts AL, Barr FE, Gregory DF, et al. (2004). Computerized Physician Order Entry and Medication Errors in a Pediatric Critical Care Unit. Pediatrics.
Pringle M, Robins S, Brown G. (1985). Computer assisted screening: effect on the patient and his consultation. Br Med J (Clin Res Ed).
Pringle M, Robins S, Brown G. (1986). Timer: a new objective measure of consultation content and its application to computer assisted consultations. Br Med J (Clin Res Ed).
Quattlebaum TG, Darden PM, Sperry JB. (1991). Effectiveness of computer-generated appointment reminders. Pediatrics.
Ramaswamy MR, Chaljub G, Esch O, et al. (2000). Continuous speech recognition in MR imaging reporting: advantages, disadvantages, and impact. AJR Am J Roentgenol.
Raschke RA, Gollihare B, Wunderlich TA, et al. (1998). A computer alert system to prevent injury from adverse drug events: development and evaluation in a community teaching hospital. JAMA.
Raynor DK, Booth TG, Blenkinsopp A. (1993). Effects of computer generated reminder charts on patients' compliance with drug regimens. BMJ.
Rethans JJ, Hoppener P, Wolfs G, et al. (1988). Do personal computers make doctors less personal?. Br Med J (Clin Res Ed).
Revere D, Dunbar PJ. (2001). Review of computer-generated outpatient health behavior interventions: clinical encounters “in absentia”. J Am Med Inform Assoc.
Rind DM, Safran C, Phillips RS, et al. (1994). Effect of computer-based alerts on the treatment and outcomes of hospitalized patients. Arch Intern Med.
Robbins JA, Dickinson WA, Bartel AG, et al. (1993). Lipid management program: results of applying national guidelines in a private practice. South Med J.
Robson J, Boomla K, Fitzpatrick S, et al. (1989). Using nurses for preventive activities with computer assisted follow up: a randomised controlled trial. BMJ.
Rodman JH, Jelliffe RW, Kolb E, et al. (1984). Clinical studies with computer-assisted initial lidocaine therapy. Arch Intern Med.
Rogers MA, Small D, Buchan DA, et al. (2001). Home monitoring service improves mean arterial pressure in patients with essential hypertension. A randomized, controlled trial. Ann Intern Med.
Rollman BL, Hanusa BH, Gilbert T, et al. (2001). The electronic medical record. A randomized trial of its impact on primary care physicians' initial management of major depression [corrected]. Arch Intern Med.
Rollman BL, Hanusa BH, Lowe HJ, et al. (2002). A randomized trial using computerized decision support to improve treatment of major depression in primary care. J Gen Intern Med.
Rosado B, Menzies S, Harbauer A, et al. Accuracy of computer diagnosis of melanoma: a quantitative metaanalysis. Arch Dermatol 2003;139(3):361–7; discussion 366. [Rec#: 355]
Rosenfeld BA, Dorman T, Breslow MJ, et al. (2000). Intensive care unit telemedicine: alternate paradigm for providing continuous intensivist care. Crit Care Med.
Rosenstein AH. (1999). Measuring the benefit of performance improvement and decision support. Am J Med Qual.
Rosenstein AH. (2000). Measuring the benefits of clinical decision support: return on investment. Pharm Pract Manag Q.
Rosser WW, Hutchison BG, McDowell I, et al. (1992). Use of reminders to increase compliance with tetanus booster vaccination. CMAJ.
Rossi RA, Every NR. (1997). A computerized intervention to decrease the use of calcium channel blockers in hypertension. J Gen Intern Med.
Ruiz R, Borches D, Gonzalez A, et al. (1993). A new sodium-nitroprusside-infusion controller for the regulation of arterial blood pressure. Biomed Instrum Technol.
Ryff-de Leche A, Engler H, Nutzi E, et al. (1992). Clinical application of two computerized diabetes management systems: comparison with the log-book method. Diabetes Res.
Safran C, Rind DM, Davis RB, et al. (1995). Guidelines for management of HIV infection with computer-based patient's record. Lancet.
Sanders DL, Miller RA. The effects on clinician ordering patterns of a computerized decision support system for neuroradiology imaging studies. Proc AMIA Symp 2001;583–7. [Rec#: 112]
Schriger DL, Baraff LJ, Buller K, et al. (2000). Implementation of clinical guidelines via a computer charting system: effect on the care of febrile children less than three years of age. J Am Med Inform Assoc.
Schriger DL, Baraff LJ, Rogers WH, et al. (1997). Implementation of clinical guidelines using a computer charting system. Effect on the initial care of health care workers exposed to body fluids. Jama.
Selmi PM, Klein MH, Greist JH, et al. (1990). Computer-administered cognitive-behavioral therapy for depression. Am J Psychiatry.
Shea S, DuMouchel W, Bahamonde L. (1996). A meta-analysis of 16 randomized controlled trials to evaluate computer-based clinical reminder systems for preventive care in the ambulatory setting. J Am Med Inform Assoc.
Shiffman RN, Liaw Y, Brandt CA, et al. (1999). Computer-based guideline implementation systems: a systematic review of functionality and effectiveness. J Am Med Inform Assoc.
Shojania KG, Yokoe D, Platt R, et al. (1998). Reducing vancomycin use utilizing a computer guideline: results of a randomized controlled trial. J Am Med Inform Assoc.
Simkins CV, Wenzloff NJ. (1986). Evaluation of a computerized reminder system in the enhancement of patient medication refill compliance. Drug Intell Clin Pharm.
Simon GE, VonKorff M, Rutter C, et al. (2000). Randomised trial of monitoring, feedback, and management of care by telephone to improve treatment of depression in primary care. BMJ.
Singh AK, Moidu K, Trell E, et al. (1992). Impact on the management and delivery of primary health care by a computer-based information system. Comput Methods Programs Biomed.
Steele MA, Bess DT, Franse VL, et al. (1989). Cost effectiveness of two interventions for reducing outpatient prescribing costs. DICP.
Strecher VJ, Kreuter M, Den Boer DJ, et al. (1994). The effects of computer-tailored smoking cessation messages in family practice settings. J Fam Pract.
Sullivan F, Mitchell E. (1995). Has general practitioner computing made a difference to patient care? A systematic review of published reports. Bmj.
Sun J, Chang MW. (1995). Initialization of warfarin dosages using computer modeling. Arch Phys Med Rehabil.
Szilagyi PG, Rodewald LE, Savageau J, et al. (1992). Improving influenza vaccination rates in children with asthma: a test of a computerized reminder system and an analysis of factors predicting vaccination compliance. Pediatrics.
Tape TG, Campbell JR. (1993). Computerized medical records and preventive health care: success depends on many factors. Am J Med.
Teich JM, Merchia PR, Schmiz JL, et al. (2000). Effects of computerized physician order entry on prescribing practices. Arch Intern Med.
Theil DR, Stanley TE=, White WD, et al. (1993). Midazolam and fentanyl continuous infusion anesthesia for cardiac surgery: a comparison of computer-assisted versus manual infusion systems. J Cardiothorac Vasc Anesth.
Thiru K, Hassey A, Sullivan F. (2003). Systematic review of scope and quality of electronic patient record data in primary care. Bmj.
Threet E, Fargues MP. (1999). Economic evaluation of voice recognition for the clinicians' desktop at the Naval Hospital Roosevelt Roads. Mil Med.
Tierney WM, Hui SL, McDonald CJ. (1986). Delayed feedback of physician performance versus immediate reminders to perform preventive care. Effects on physician compliance. Med Care.
Tierney WM, McDonald CJ, Hui SL, et al. (1988). Computer predictions of abnormal test results. Effects on outpatient testing. JAMA.
Tierney WM, McDonald CJ, Martin DK, et al. (1987). Computerized display of past test results. Effect on outpatient testing. Ann Intern Med.
Tierney WM, Miller ME, McDonald CJ. (1990). The effect on test ordering of informing physicians of the charges for outpatient diagnostic tests. N Engl J Med.
Tierney WM, Miller ME, Overhage JM, et al. (1993). Physician inpatient order writing on microcomputer workstations. Effects on resource utilization. JAMA.
Timmermans D, van Bockel H, Kievit J. (2001). Improving the quality of surgeons' treatment decisions: a comparison of clinical decision making with a computerised evidence based decision analytical model. Qual Health Care.
Turner BJ, Day SC, Borenstein B. (1989). A controlled trial to improve delivery of preventive care: physician or patient reminders?. J Gen Intern Med.
Turner RC, Peden JG, O'Brien K. (1994). Patient-carried card prompts vs computer-generated prompts to remind private practice physicians to perform health maintenance measures. Arch Intern Med.
Valancy J. (2002). How much will that EMR system really cost?. Fam Pract Manag.
van den Hoogen JP, van Ree JW. (1990). Preventive cardiology in general practice: computer-assisted hypertension care. J Hum Hypertens.
van den Nieuwenhuyzen MC, Engbers FH, Burm AG, et al. (1995). Computer-controlled infusion of alfentanil versus patient-controlled administration of morphine for postoperative analgesia: a double-blind randomized trial. Anesth Analg.
van Wijk MA, van der Lei J, Mosseveld M, et al. (2001). Assessment of decision support for blood test ordering in primary care. a randomized trial. Ann Intern Med.
Verner D, Seligmann H, Platt S, et al. (1992). Computer assisted design of a theophylline dosing regimen in acute bronchospasm: serum concentrations and clinical outcome. Eur J Clin Pharmacol.
Vincent EC, Hardin PA, Norman LA, et al. The effects of a computer-assisted reminder system on patient compliance with recommended health maintenance procedures. Proc Annu Symp Comput Appl Med Care 1995;656–60. [Rec#: 720]
Walker J, Pan E, Johnston D, et al. The value of health care information exchange and interoperability. Health Affairs 2005;w5.10. [Rec#: 987]
Walton R, Dovey S, Harvey E, et al. (1999). Computer support for determining drug dose: systematic review and meta-analysis. Bmj.
Wang SJ, Middleton B, Prosser LA, et al. (2003). A cost-benefit analysis of electronic medical records in primary care. Am J Med.
Warshawsky SS, Pliskin JS, Urkin J, et al. (1994). Physician use of a computerized medical record system during the patient encounter: a descriptive study. Comput Methods Programs Biomed.
Weingarten MA, Bazel D, Shannon HS. (1989). Computerized protocol for preventive medicine: a controlled self-audit in family practice. Fam Pract.
Wells BJ, Lobel KD, Dickerson LM. (2003). Using the electronic medical record to enhance the use of combination drugs. Am J Med Qual.
White KS, Lindsay A, Pryor TA, et al. (1984). Application of a computerized medical decision-making process to the problem of digoxin intoxication. J Am Coll Cardiol.
White RH, Hong R, Venook AP, et al. (1987). Initiation of warfarin therapy: comparison of physician dosing with computer-assisted dosing. J Gen Intern Med.
White RH, Mungall D. (1991). Outpatient management of warfarin therapy: comparison of computer-predicted dosage adjustment to skilled professional care. Ther Drug Monit.
Willcourt RJ, Pager D, Wendel J, et al. (1994). Induction of labor with pulsatile oxytocin by a computer-controlled pump. Am J Obstet Gynecol.
Willson D, Ashton C, Wingate N, et al. Computerized support of pressure ulcer prevention and treatment protocols. Proc Annu Symp Comput Appl Med Care 1995;646–50. [Rec#: 721]
Wilson AL, Hill JJ, Wilson RG, et al. (1997). Computerized medication administration records decrease medication occurrences. Pharm Pract Manag Q.
Wilson GA, McDonald CJ, McCabe GP. (1982). The effect of immediate access to a computerized medical record on physician test ordering: a controlled clinical trial in the emergency room. Am J Public Health.
Wong DH, Gallegos Y, Weinger MB, et al. (2003). Changes in intensive care unit nurse task activity after installation of a third-generation intensive care unit information system. Crit Care Med.