# Appendix E: Peer Reviewers Comments

## “Health Information Technology - Costs and Benefits”

[underlined: Section] | [underlined: Page] | [underlined: Comment] | [underlined: Response]
4. Conclusions | | The overall cautious tone of the conclusions is appropriate given the limitations of the data. | No response needed.
4. Conclusions | | Use IOM framework of HIT functions to outline conclusions about which are most likely to produce benefits. | This is a desirable goal, but one we do not think is achievable with published data, because the benefit of functionalities are context specific, dependent on other functionalities of the HIT system, and the current state of the organization.
| | Report could do more to make its findings useful in the current context of decisions re. HIT - which systems should be implemented to support which functions.
Overall | | What savings will derive from better quality, to whom do those savings accrue, and over what time frame? | We have indicated that existing data do not answer this question.
1. Introduction | 1 | Few data about stand-alones making a difference. Second paragraph, after “These systems,” please remove “used as stand-alone clinical decision support tools, or” | Done.
1. Introduction | 3 | Fourth par, after “Unless they have most of the business for that organization,” add “or agree to collaborate” Also, remove definition of “free rider” problem. | Done.
1. Introduction | 5 | Not fair to impugn prior studies without specifying all? in advance. Moreover, most journals wouldn't publish the articles if you added more description of components. Please add caveats. | We are not meaning to impugn studies, only specifying what we and others consider important components of an HIT “intervention.” We added a caveat.
1. Introduction | 6 | Regarding HIT articles, would need some standards about how to do what is expected. Standard is to provide bed size, academic/ not. I don't disagree that more info would be helpful. | No response needed.
| | | We all agree we need a CONSORT like statement for HIT implementation research.
3. Results | 13 | Second paragraph “..furthermore, it is not possible to calculate the cost of the development of an HIT system, since this process has occurred over many years.” Too gross a generalization. Sometimes you add a module quickly. Replace “not possible” with “challenging.” Change to “since this process often has occurred over..” | We added “as a whole” to indicate we are referring to the main HIT system, not the addition of a single component.
3. Results | 13 | paragraph 2, before last sentence, add “They are not commercially available from a vendor, and vendors supply most HIT systems in the U.S.” | Done.
3. Results | 14 | “No study evaluated an HIT system with at least 4 of the 8 categories of functionality.” You might list the categories here or explain. | We added this information.
3. Results - EHR and ambulatory Care | 21 | Do you just mean ambulatory EHRs? You have left out lots of inpatient studies. | Yes, this section focuses only on ambulatory EHRs.
3. Results - EHR and ambulatory care | 24 | “Evaluating the effects of EHR adoption was itself a form of structural change in this study.” Please reword, unclear. | This section has been entirely rewritten in an attempt to make this more clear.
| | What about the studies on preventive care? Should explain why omitted.
3. Results - Economic benefits of EHR | 36 | 2nd par - can you repeat size to provide perspective? | Done.
3. Results - Economic benefits of HER | 37 | Should make separate point about importance of interoperability and that it needs to be machine level for high value. | We have included a sixth point to highlight the importance of interoperability.
3. Results -barriers | 41 | Add cites: Lee, F, Journal of American Medical Informatics Assoc Shu K, in MEDINFO proceedings, 2005 Pizziferri, et al 2005 These may be too recent for your entry criteria. | We were unable to obtain (Lee, F, Journal of American Medical Informatics Assoc) & (Shu K, in MEDINFO proceedings, 2005). We added the Pizziferri article to our section on barriers.
3. Results -barriers | 42 | Last paragraph - I don't think you should close with this. This editorial overall is about as evidence free as such things get. | We deleted this text.
4. Limitations | 45 | 1st paragraph “Most of this information is absent for most published studies of HIT.” You should say why journals have word limits, and standards for publication. | We added a caveat for this.
4. Future research | 47 | “This will require the development of high quality data collection instruments that will be feasible to use before, during and after the implementation process.” I don't think this will help. | We changed this to “published standards for such reports.”
4. Future research | 48 | #6 “Well-designed studies are needed to empirically demonstrate the benefit of HIT in improving patient safety not only in the hospital environment, but also in ambulatory settings.” These will be published soon. | We look forward to it.
4. Future research | 49 | Add “support for academic investigators to partner with such organizations" (i.e. non-academic centers, provider orgs) | Done.
4. Future research | 50 | “Provide research support and expertise to grantee organizations lacking a built-in research infrastructure.” Not realistic - won't happen. Suggest omitting. | We changed the wording of this, to more strongly emphasize a public-private partnership.
4. Conclusions | vi | “We identified no hypothesis testing study of HIT that assessed a system of broad functionality which included sufficient cost data and organizational context information to allow generalization to other health care settings.” - What about the Regenstrief CPOE study? Suggest dropping this statement. | We meant cost data in terms of acquisition and implementation costs of the entire system, not a single component. We have added this information to this sentence.
4. Conclusions | | I think you are too critical of the published literature on HIT re. inclusions of administrative info, given lack of a standard and word limits on published papers, though I agree it is a good idea. | We added caveats to this.
Overall | | This is truly a stellar piece of work. | No response needed
1. Introduction | 1 | “The use of health information technology (HIT) holds tremendous promise in improving the efficiency, cost-effectiveness, quality and safety of medical care delivery in our nation's healthcare system.” see comment on conclusions. Unless tied to a source, such as an IOM report, this statement is more appropriate to a policy paper than an evidence report. | We changed this to “has been promoted as having...”
1. Introduction | 5 | HIT interventions have a fifth component: communication (see in text comment) | We have added communication to the four existing components as a cross cutting component.
3. Results - Pediatrics | 21 | Tone and content of the 3 section summaries (within peds) are very different. Make more consistent. | In this revision, we have used a medical editor to try and make the report's tone more consistent.
3. Results - EHR and ambulatory | 22 | “studies that were accepted after screening, review, and reconciliation” unclear | This was reworded.
3. Results - EHR and ambulatory | 32 | need to harmonize content and tone. Need to acknowledge extremely small number of studies, almost 50% are at same institution | Done.
3. Results - Economic benefits of EHR | 33 | use of “we” is not consistent across report | We tried to make this more consistent.
3. Results - Economic benefits of HER | 34 | health care information exchange and interoperability - HIEI - this seems like an unhelpful acronym | Done.
4. Future research | 50 | This section seems unfinished in terms of development of ideas. | This particular reviewer received an early, unedited version of report. The future research section has been more fully developed in this draft.
Preface | iii | Add that ODPHR provided additional funding | We have included all funding sources.
4. Conclusions | viii | “HIT has the potential to enable a dramatic transformation in the delivery of health care, making it safer, more effective, and more efficient.” I think this sentence should be reconsidered in light of the conclusion sections of the case studies. As an evidence report and not a policy paper, the sentence should more closely reflect the findings, which are that the evidence is very limited, from a very small number of studies and organizations, and is inconclusive. The findings are suggestive of future research more than anything else and of the need to systematize data collection about organizations and contexts in order to be able to make comparisons across studies and settings, per the final sentence of this section. Perhaps another point to make is that cost/benefit analysis may be a relatively recent way of looking at the decision-making. The analysis could suggest the types of information required to collect during evaluation so this type of comparative analysis can be done in the future | We revised this statement to state that predictive analyses suggest that HIT has this potential.
Overall | 1 | I read the report with pleasure. The database is excellent and useful. | No response needed.
2. Methods | 2 | Most reviews and ‘searches for evidence’ on benefits (either financial or otherwise) of HIT in the health care literature fall into the trap of treating a HIT as just another ‘new intervention’ that has to be evaluated using RCTs or its somewhat lesser equals. The important contribution of this report is that it has picked up the message... that HIT cannot be treated that way. | No response needed.
2. Methods | 3 | ...any ‘IT innovation’ is highly context-specific. There are so many key variables at stake, the authors argue, that no overall review is possible. Therefore, the authors revert to creating an interactive database, and giving three narrative reviews of substudies in particular contexts, as ‘illustrative of the uses of the interactive database’. Given the job-definition the authors have chosen, this is a wise and defendable decision. Yet I would like to raise the question whether the authors have not tied their hands behind their back by learning only half the lesson of how one should approach the question of the ‘costs and benefits of HIT’ when HIT implementations are truly seen as organizational change events. | No response needed.
Overall | 4 | This report candidly and powerfully lays out the dilemmas involved in the questions it sets out to answer. Simultaneously, however, I feel that it could have made a stronger step forward in arguing for a REPHRASING of the question for ‘proof’ for ‘benefits’ than it currently does. | We have added that the organizational context and organizational readiness to change are important components for HIT implementation.
| | ..the important question would be whether the technology technically does what it promises to do (which is a question dependent on the specific application in question) and whether the organization is subsequently ‘ready’ to use this technology in such a way that it may reap these benefits. The latter question is about proper organizational change, about creating a ‘fit’ between the technology and the organization which will generate these potential benefits. Again, nobody in that world would consider asking for RCTs or other such designs. The potential benefit, after all, is plain common sense; the question is whether these specific instances (technology and organization) will be able to yield these benefits. That is a substantially different question from interventions such a novel drug where it is NOT plain common sense whether it will yield improved outcomes compared to a placebo or its competitor drugs. The whole idea of a RCT is brilliantly designed to answer this particular question, and to avoid all other potential confounding variables from interfering with this core question. Whether a particular organization will realize the benefits that such ‘common sense’ innovations may yield is ultimately a managerial question, just like some industries succeeded in strategically reinventing their businesses through IT, while others mainly introduced it as a somewhat smarter way of doing the same thing.
General | | I see absolutely no discussion in the main text to support the statement about lack of evidence for ambulatory EHRs and improving quality by making it more consumer and patient-centric. [I have] the desire to see more research on the costs and benefits to patients of HIT. | We have added a new section, “Health Information Technology and Patient Centeredness”
| | The dearth of research on the value of HIT to the patient and the consumer, and the value of HIT to healthcare quality through more patient-centric focus, should be elevated in the discussion section of the report
1. Introduction | 2 | 2nd para - isn't there some impact on costs, ie. increasing revenue by providing more vaccinations? Would this revenue be offset by reduced hospitalizations? | We have re-done this example to make it more clear.
1. Introduction | 3 | 4th para - add: The gains to HMOs of better care will be sure when capitation payments are risk adjusted. | We have added the sentence: “The gains to HMOs of better care will be more certain when capitation payments are adequately risk adjusted.”
1. Introduction | 3 | Remove comment on “free rider” problem. | We have explained this in more detail.
1. Introduction | 3 | After “insurers might want to subsidize it in part” add: i.e. based on the payer's share of the provider's case mix. | We have added, “i.e. based on the insurer's share of the provider's case-load”
1. Introduction | 4 | “There are financial aspects to many of these non-monetized items. For example, the intervention may reduce the cost of meeting a preexisting reporting requirement.” Not sure of the point, given that even nonprofits ..must stay in business. | Agreed, but many things are done in health care that have non-monetary benefits. We are simply making that point.
2. Methods | 9 | Report “Advanced Technologies to Low Health Care Costs and Improve Quality” - what settings were discussed? | Settings of care have been added to the sentence, (inpatient and ambulatory care).
2. Methods | 9 | JAMIA meta-analysis on computer based clinical reminder systems - what settings were discussed? | Settings of care have been added to the sentence, (ambulatory care).
3. Results - EHR and ambulatory | 20 | Structure-process-outcome framework did not fit with types of outcomes discussed. Framework also interrupted the flow of discussion. Please rewrite | We have restructured the framework by study and structure-process-outcome framework to allow for more fluid discussion.
3. Results - EHR and ambulatory | 20 | 3rd par - “Therefore, the roles of EHRs in improving quality is unclear at this time.” However, later on the authors state that there is evidence of improvements in quality. “5 of the 7 assessed quality through an analysis of some type of outcome.” This conflicts with previous paragraph “6 of the 7 assessed quality with respect to some type of outcome.” | We have entirely rewritten this section to satisfy these comments.
| | Par 3 - What is meant by “patient charts became available”? Electronic charts?
3. Results - Economic benefits of HER | 31 | Somewhere early you need to define what constitutes an EHR, minimum functionality, etc. | This is now done in the introductory paragraph.
3. Results - Economic benefits of HER | 31 | Do you mean to imply that decision support is not part of EHR? | This is better explained in the introductory paragraph.
3. Results - Economic benefits of HER | 31 | Strengthen the discussion of evidence that emerges from each of the following studies that support an “economic appraisal” of the EHR component. | We have expanded this discussion.
3. Results - Economic benefits of HER | 33 | 1st Par - Provide an example or two about how these studies quantified / monetized costs and benefits. | How these variables were defined is now indicated in the text.
3. Results - Economic benefits of HER | 33 | Be consistent - either refer to the study location or don't. You mention Kaiser and Partners but not the other study sites. | We have changed this for consistency.
3. Results - Economic benefits of HER | 34 | First study - ($9700 per provider) - what were the component parts of the EHR system? | We now provide the component parts of the EHR system.
3. Results - Economic benefits of HER | 37 | Conclusion 1 - What about information exchange capabilities? | We added this as point 6 under Conclusion.
3. Results - Economic benefits of HER | 37 | Conclusion 5 - Revise last sentence to: Changes to the current health care financing system would be required to realize all quantifiable benefits of EHR implementation. | We have changed the last sentence to, “Realizing all quantifiable benefits of EHR implementation would require changes to the current health care financing system.”
4. Conclusions | 47 | Change “Economic value” heading to “Economic value of HIT and EHR Implementation” | This has been changed to “Economic Value of an EHR System”
4. Conclusions | 47 | Conclusion 4. Under economic value - change 1st sentence to “The positive economic estimates for EHR system implementation are encouraging but at this time are based on limited evidence.” | Done.
4. Conclusions | 47 | Add conclusion “There is some evidence regarding the positive economic value of implementing component parts of EHRs.” | We have added this sentence to this section.
4. Future research | 47 | Change 1 to "Available evidence highlights the potential for EHRs to impact quality of care. However, a more systematic, evidence based understanding of the role of EHRs in quality improvement in ambulatory care and other settings is needed. | We have changed this sentence to “Available evidence highlights the potential for ambulatory EHRs to affect quality of care. However, a more systematic, evidence-based understanding of the role of ambulatory EHRs in quality improvement is needed. This information is critical not only to facilitate adoption, but also to enhance the benefits adopters realize from EHR implementation.”
4. Future research | 48 | Remove “ambulatory” before EHRs in all the sentences. | Done.
Preface | iv | Health Communication and Telehealth provided funding - who is this? | This was an incorrect reference to our funders.
assorted | | typos, language usage | We have made the suggested revisions.
Overall | | This is a wonderful review and a very intuitive organization of key findings. | No response needed.
Overall | | Given our national predilections for leaping before we look, what you have compiled and made accessible will nonetheless provide a more valuable guide for pioneers than pure intuition. | No response needed.
1. Introduction | | Intro focuses the report on costs, benefits, and barriers to HIT. Organization of the report and conclusions should specifically focus on those areas, or intro should be changed. | We have restructured the organization of the report.
4. Conclusions | | Are there any recommendations for effective metrics to be tracked for organizations implementing HIT? | We have added a conclusion that the field needs standards in this area.
Overall | | Add more on potential disconnect between who is funding and who is benefiting, i.e. physician adoption at a community based medical center is distinctly different than at an academic medical center based on financial relationships. | We have added to the text and the conclusion that “who pays” and “who benefits” is a central question and that, except for systems like Kaiser and the VA, it is not possible with published data to reach definitive conclusions, other than to state the potential for a mismatch exists.
Overall | | There is a problem knowing when to “jump in” i.e. when will interfaces be optimized and products ready. | We agree this is a problem, and one there is scant evidence regarding
Overall | | High quality is less of an issue when patients do not have the ability to choose / access all providers. | No response needed.
Overall | | A simple projected case study might be illustrative, i.e.. adding Fine Pneumonia Protocols for pneumonia admission into CPOE or EHR. | We discussed this idea but decided not to include this, there are dozens of such case studies published, which are included in our database. Interested readers may find them there.
Overall | | Report is terrific. | No response needed.
Overall | | Comment on how this report extends or compliments recent JAMA review. | It extends the recent JAMA review by nothing that the HIT literature, in general, and not just the decision support literature, is dominated by a few centers evaluating their own products.
| | | The generalizability of the results of these evaluations is questionable, for the reasons given.