# Appendix D: List of TEP Members Who Provided Comments

David Bates, MD, MSc | David Atkins
Chief, General Medicine | Agency for Healthcare Research and Quality
Brigham and Women's Hospital | 540 Gaither Road
620 Tremont Street, Room BC3-002M | Rockville, Maryland 20850
Boston, MA 02120-1613 | 301-427-1618
617-732-5650 | 301-427-1520 (fax)
617-732-7072 (fax) | datkins@ahrq.gov
dbates@partners.org
Marc Berg | [underlined: Mary Jo Deering, Ph.D].*
Prof. Dr. Marc Berg, MA, MD, PhD | Director for Informatics Dissemination
Chair of Dept. of Social Medical Sciences | NCI Center for Bioinformatics
Institute of Health Policy and Management | National Cancer Institute
Erasmus University Rotterdam | National Institutes of Health, USDHHS
P.O. Box 1738 | 6116 Executive Blvd. - #400
3000 DR Rotterdam | Rockville, MD 20852
The Netherlands | Phone: 301-594-1273
Phone: ++31-10-4088531 / 4088525 | Fax: 301-480-3441
Fax: ++31-10-4089094 | E-mail: deeringm@mail.nih.gov
M.Berg@bmg.eur.nl
Jennie Harvell | Scott Weingarten, MD, MPH
Senior Policy Analyst | Chief Medical Officer
U.S. Department of Health and Human Services | Zynx Health, Inc.
Humphrey Building | 9100 Wilshire Blvd., Suite 655-E
200 Independence Avenue SW | Beverly Hills, CA 90210
Washington, DC 20201 | 310-247-7700
202-690-6443 | 310-247-710 (fax)
202-401-7733 (fax) | weingarten@zynx.com
jennie.harvell@hhs.gov
Arnold Milstein, MD, MPH | Elliott Sternberg, MD
Principal and Consultant | Senior Vice President and
William M. Mercer, Inc. | Chief Medical Officer
3 Embarcadero Center | St. Joseph Health System
Suite 1500 | 500 S. Main Street, Suite 900
San Francisco, CA 94111 | Orange, CA 92868
415-743-8803 | 714-347-7841
415-743-8950 (fax) | esternbe@corp.stjoe.org
arnold.milstein@mercer.com
Cynthia Baur
Office of Public Health and Science, Office of Disease Prevention and Health Promotion
HHS/OS/OPHS/ODPHP
738G Humphrey Building
telephone: (202) 205-2311
telefax: (22) 205-0463
e-mail:cbaur@osophs.dhhs.gov