# Appendix C: Health Information Technology Round Two Screener

Article ID: 0000

Reviewer: ______________

Reviewers:

Assigned on:

Check all that apply on each question. To change pre-screener data from “checked” to “unchecked” please write “uncheck” next to the appropriate box.

1. What are the one or two main HIT elements being tested?
Computerized Provider Order Entry | □
Electronic Health Record | □
Decision Support | □
Results Reporting/Viewing Systems | □
Electronic Prescribing (incl. Barcoding) | □
Mobile Computing | □
Data Exchange Networks/ Community Health Information Network | □
Patient Decision Support/ Consumer Health Informatics | □
Communication Systems | □
Administrative | □
Knowledge/ Information Retrieval Systems | □
Data Collection/ Data Summary Systems | □
Telemedicine | □
HIT in general | □
Other (specify: ________________________) | □
Not HIT | □
N/A, N/R | □
2. Which IOM categories does the HIT address?
Health information and data storage | □
Results management | □
Order entry management | □
Decision support | □
Electronic communication and connectivity | □
Patient support | □
Administrative processes | □
Reporting and population health management | □
N/A, N/R | □
3. What are the types of healthcare organization settings?
Hospital/inpatient | □
Outpatient/ambulatory | □
Integrated delivery Network (IDN) | □
Emergency room | □
Nursing home | □
Patient home | □
Pediatrics | □
Pharmacy | □
Internet | □
Other setting (specify: __________________) | □
N/A, N/R | □
4. What is the article's purpose? | | [Circle one]
Descriptive
1. Qualitative | 2. Quantitative | 3. Other descriptive
Hypothesis testing:
With Intervention, with concurrent comparison group:
4. RCT | 5. CCT | 6. Cntrl. Before/After
With intervention, without concurrent comparison group:
7. Pre-Post | 8. Time series | 9. Historical control
No intervention
10. Cross-sectional | 19. Case study with concurrent control
Other hypothesis testing:
11. Other hypothesis testing
Predictive analysis
12. Cost-effect. | 13. Cost-benefit | 14. Other pred.analysis
Review
15. Non-systematic | 16.Systematic/MA
Other Purpose
18. Other (specify: _________________)
5. Does this article report data from any of the following systems?
Intermountain | □
Partners | □
Regenstrief | □
VA | □
UK's NHS | □
Kaiser | □
Vanderbilt University | □
N/A, N/R | □
6. Which outcomes are measured (numerically reported) in the article?
Impact on patient safety | □
Impact on patient satisfaction | □
Impact on health care effectiveness and quality | □
Impact on efficiency, utilization, and costs | □
Time: Admin □; Nurs. □; Phys. □; Pt □; NOS □
Impact on healthcare access | □
Other (specify:_____________________) | □
N/A, N/R | □
7. Are barriers or facilitators the main focus of the paper, and/or are numerical results given?
| [Circle One]
Yes | 1
No | 2
N/A, N/R | 8
8. What years did the research take place?
(Enter 4-digit years. N/A, N/R: enter 9999)
Year began | Year ended
NOTES:
□ Check here if this article should be a Star Article Candidate